# Peer Reviewers

List of peer reviewers to be provided by AHRQ.