# List of Excluded Studies

Table D-1 Excluded full articles

Study | Reason(s) for Exclusion
Yi et al. 2010^313^ | Cancer mortality study.
Author(s) not listed 1988^103^ | Clinical meeting article.
Purohit et al. 2005^40^ | Clinical meeting article.
Scheppach et al. 1999^314^ | Clinical meeting article.
Seitz et al. 1992^315^ | Clinical meeting article.
Weisburger 1992^316^ | Clinical meeting article.
Kleinjans et al. 1996^317^ | Contents of alcoholic beverage.
Potter et al. 1982^318^ | Correlation analysis study.
Siegmund et al. 2003^319^ | Description of animal models in gastrointestinal alcohol research.
Aye et al. 2004^320^ | Invasion of breast cancer cells.
Luo 2006^321^ | Invasion of breast cancer cells.
Luo and Miller 2000^322^ | Invasion of breast cancer cells.
Ma et al. 2003^323^ | Invasion of breast cancer cells.
Meng et al. 2000^324^ | Invasion of breast cancer cells.
McGarrity and Nelson 1986^325^ | Letter to editor.
Larsen 1993^326^ | News report publication.
Colombo et al. 2001^327^ | No outcome of interest.
Fiala et al. 1987^328^ | No outcome of interest.
Zedeck 1980^329^ | No outcome of interest.
Holford 1987^5^ | Pharmacokinetic study.
Weisburger and Wynder 1984^330^ | Review article.
Agrawal et al. 2007^331^ | Review article.
Alberts 2002^332^ | Review article.
Ambrosone 2000^333^ | Review article.
Arasaradnam et al. 2008^334^ | Review article.
Author(s) not listed 2000^1^ | Review article.
Author(s) not listed 2008^27^ | Review article.
Author(s) not listed 1994^335^ | Review article.
Baan et al. 2007^2^ | Review article.
Bailey 2003^336^ | Review article.
Blot 1992^337^ | Review article.
Boffetta and Hashibe 2006^338^ | Review article.
Bosetti et al. 2002^339^ | Review article.
Brown 2005^340^ | Review article.
Campos et al. 2005^341^ | Review article.
Chhabra et al. 1996^342^ | Review article.
Correa Lima and Gomes-da-Silva 2005^343^ | Review article.
Dossus and Kaaks 2008,^344^ | Review article.
Dumitrescu and Cotaria 2005^345^ | Review article.
Ferguson et al. 2005^346^ | Review article.
Filion 2002^347^ | Review article.
Forman et al. 2004^348^ | Review article.
Fraumeni 1979^349^ | Review article.
Gago-Dominguez et al. 2007^350^ | Review article.
Giovannucci 2002^351^ | Review article.
Goodwin 2008^352^ | Review article.
Hamid et al. 2009^353^ | Review article.
Heavey et al. 2004^354^ | Review article.
Homann et al. 2005^355^ | Review article.
Huxley et al. 2007^356^ | Review article.
Key and Verkasalo 1999^357^ | Review article.
Key et al. 2004^42^ | Review article.
Kim et al. 2007^358^ | Review article.
Klatsky 2001^359^ | Review article.
La Vecchia 1989^360^ | Review article.
Lands 1998^361^ | Review article.
Ledermann 1955^362^ | Review article.
Li and Lai 2009^363^ | Review article.
Lieber 2000^364^ | Review article.
Lindhal 1992^365^ | Review article.
Longnecker 1995^366^ | Review article.
Longnecker 1995^367^ | Review article.
Lowenfels 1990^368^ | Review article.
Mason and Choi 2005^369^ | Review article.
Nagy 2004^9^ | Review article.
Nanri et al. 2007^370^ | Review article.
O’Hanlon 2005^35^ | Review article.
Payne 1990^371^ | Review article.
Perse and Cerar 2007^84^ | Review article.
Porter 1993^372^ | Review article.
Porter 1995^373^ | Review article.
Poschl and Seitz 2004^24^ | Review article.
Poschl et al. 2004^374^ | Review article.
Pufulete et al. 2003^375^ | Review article.
Purohit 2000^376^ | Review article.
Rampersaud et al. 2002^377^ | Review article.
Rogers and Conner 1986^378^ | Review article.
Rogers et al. 1993^379^ | Review article.
Rothman et al. 1995^380^ | Review article.
Sakar et al. 2001^381^ | Review article.
Salaspuro 1996^20^ | Review article.
Salaspuro and Mezey 2003^382^ | Review article.
Schatzkin and Longnecker 1994^43^ | Review article.
Secretan et al. 2009^17^ | Review article.
Seitz and Becker 2007^383^ | Review article.
Seitz and Homann 2007^384^ | Review article.
Seitz and Maurer 2007^385^ | Review article.
Seitz and Poschl 1997^386^ | Review article.
Seitz et al. 1994^387^ | Review article.
Seitz et al. 2005^369^ | Review article.
Seitz et al. 1998^388^ | Review article.
Siegmund et al. 2006^389^ | Review article.
Simanowski et al. 1995^390^ | Review article.
Stoll 1999^391^ | Review article.
Tan et al. 2006^392^ | Review article.
Taylor and Rehm 2006^393^ | Review article.
Thies and Siegers 1989^394^ | Review article.
Tsigris et al. 2007^395^ | Review article.
Ulrich 2007^396^ | Review article.
Walker and Burkitt 1976^397^ | Review article.
Wang 2003^398^ | Review article.
Wang 2005^399^ | Review article.
Weisburger et al. 1981^400^ | Review article.
Weisburger 1998^401^ | Review article.
Welsch 1985^402^ | Review article.
Williams 1976^403^ | Review article.
Winawer and Shike 1992^404^ | Review article.
Wright et al. 1999^25^ | Review article.
Wynder 1977^405^ | Review article.
Wynder 1978^406^ | Review article
Nozawa et al. 2006^407^ | Study administered freeze-dried beer.
Martin et al. 2004^408^ | Study administered Resveratrol, a polyphenol found in grapes.
Gierer 1955^409^ | Study did not look at cancer causation.
Briviba et al. 2002^410^ | Study did not report on consumption/administration of ethanol.
Caderni et al. 2000^411^ | Study did not report on consumption/administration of ethanol.
Cerda et al. 1999^412^ | Study did not report on consumption/administration of ethanol.
Depeint et al. 2006^413^ | Study did not report on consumption/administration of ethanol.
Diergaarde et al. 2003^259^ | Study did not report on consumption/administration of ethanol.
Dolara et al. 2005^358^ | Study did not report on consumption/administration of ethanol.
Farah 2005^414^ | Study did not report on consumption/administration of ethanol.
Femia et al. 2005^415^ | Study did not report on consumption/administration of ethanol.
Gonthier et al. 2003^416^ | Study did not report on consumption/administration of ethanol.
Hall et al. 1991^417^ | Study did not report on consumption/administration of ethanol.
Kabat and Rohan 2007^418^ | Study did not report on consumption/administration of ethanol.
Kabat et al. 2007^419^ | Study did not report on consumption/administration of ethanol.
Lagiou et al. 2009^420^ | Study did not report on consumption/administration of ethanol.
Etique et al. 2004^421^ | Study did not report on consumption/administration of ethanol.
Linz et al. 2004^422^ | Study did not report on consumption/administration of ethanol.
Luceri et al. 2002^423^ | Study did not report on consumption/administration of ethanol.
Maciel et al. 2004^298^ | Study did not report on consumption/administration of ethanol.
Moon et al. 2006^424^ | Study did not report on consumption/administration of ethanol.
Morris and Seifter 1992^425^ | Study did not report on consumption/administration of ethanol.
Nozawa et al. 2004^426^ | Study did not report on consumption/administration of ethanol.
Nozawa et al. 2004^427^ | Study did not report on consumption/administration of ethanol.
Nozawa et al. 2005^428^ | Study did not report on consumption/administration of ethanol.
Peluso et al. 2008^429^ | Study did not report on consumption/administration of ethanol.
Reddy et al. 1997^430^ | Study did not report on consumption/administration of ethanol.
Robson et al. 2006^431^ | Study did not report on consumption/administration of ethanol.
Schrauzer et al. 1982^432^ | Study did not report on consumption/administration of ethanol.
Takechi et al. 2004^433^ | Study did not report on consumption/administration of ethanol.
Wulf et al. 2004^434^ | Study did not report on consumption/administration of ethanol.
Yamagishi et al. 2002^435^ | Study did not report on consumption/administration of ethanol.
Slattery et al. 2009^58^ | Study looked at tumor markers.
Gago-Dominguez et al. 2005^436^ | Unrelated epidemiology study.
Gaudet et al. 2005^437^ | Unrelated epidemiology study.
Giacosa et al. 2004^438^ | Unrelated epidemiology study.
Lewis et al. 2003^439^ | Unrelated epidemiology study.
Orita et al. 2004^440^ | Unrelated epidemiology study.
Schatzkin et al. 1993^441^ | Unrelated epidemiology study.
Visapaa et al. 1998^442^ | Inhibition of intracolonic acetaldehyde production by ciprofloxacin.
Vogel et al. 2007^184^ | Title correction.