# Evidence Tables

## Evidence Base for Breast Cancer

Table C-1 Summary of results from human studies on breast cancer

Study | Model | Study Design | Mechanism Examined | Amount and Duration of Ethanol and/or Acetaldehyde Exposure | Results | Conclusions as Reported by Study Authors
Hartman et al. 2005^76^ | 53 postmenopausal women | Case control | Increase levels of biomarkers of oxidative stress | Controlled diet plus each of three treatments (15 or 30 g alcohol per day or no-alcohol placebo beverage), during three 8-week periods in random order | After adjusting for body mass index (all models) and total serum cholesterol (tocopherol and isoprostane models), there was a 4.6% decrease (p = 0.02) in α-tocopherol and a 4.9% increase (p = 0.07) in isoprostane levels when women consumed 30 g alcohol/day (p = 0.06 and 0.05 for overall effect of alcohol on a-tocopherol and isoprostanes, respectively). | Moderate alcohol consumption increases some biomarkers of oxidative stress in postmenopausal women.
Dorgan et al. 2001^85^ Same as 311 | 51 healthy postmenopausal women not using hormone replacement therapy | Three-period crossover design | Elevated serum levels of estradiol, estrone, estrone sulfate, testosterone, androstenedione, progesterone, dehydroepiandrosterone (DHEA), DHEA sulfate (DHEAS), and androstenediol | 15 g or 30 g of alcohol per day or an alcohol-free placebo beverage through a three 8-week dietary period. Alcohol was supplied as 95% ethanol in 12 oz orange juice. Each dietary period was preceded by a 2- to 5-week washout period when participants did not consume any alcohol. | 15 g of alcohol/day resulted in an increase of 7.5% (95% confidence interval [CI]: −0.3 to 15.9%; p = 0.06) of estrone sulfate. 30 g of alcohol/day resulted in an increase of 10.7% (95% CI: 2.7 to 19.3%; p = 0.009) estrone sulfate 15 g of alcohol/day resulted in an increase of 5.1% (95% CI: 1.4 to 9.0%; p = 0.008) DHEAS. 30 g of alcohol/day resulted in an increase of 7.5% (95% CI: 3.7 to 11.5%; p <0.001) DHEAS | Results suggest a possible mechanism by which consumption of one or two alcoholic drinks per day by postmenopausal women could increase their risk of breast cancer.
Ginsburg et al. 1996^88^ | 12 postmenopausal women receiving oral estrogen (estradiol, 1 mg/day) and progestin (medroxy-progesterone acetate) replacement therapy were compared with 12 postmenopausal women who were not using estrogen replacement therapy (ERT). | Randomized, double-blind, placebo-controlled crossover study | Effects of alcohol ingestion on estrogens in postmenopausal women | Pineapple juice and 40% ethanol at a dose of 2.2 mL/kg of body weight (0.7 g/kg of body weight) in a total volume of 300 mL over 15 minutes | Within 50 minutes of alcohol ingestion in postmenopausal women on ERT, there was a 3-fold increase in estradiol levels from 297 to 973 pmol/L (p <0.001) No changes in estradiol following alcohol ingestion in postmenopausal women not on ERT | Acute alcohol ingestion may lead to significant and sustained elevations in circulating estradiol.
Ginsburg et al. 1995^87^ | 14 menopausal women using transdermal estradiol | Two randomized crossover studies | Effect of acute ethanol ingestion on prolactin in menopausal women using estradiol replacement | Ethanol (1 mL/kg, 95% ethanol) over 20 minutes | Alcohol when compared to isocaloric carbohydrate drink ingestion resulted in increased serum prolactin levels in both study 1 (p <0.03) and study 2 (p <0.001) | There was an increase in serum prolactin levels.
Reichman et al. 1993^86^ | 34 premenopausal women with a history of regular menstrual cycle | Randomized, diet-controlled crossover intervention | The effects of alcohol consumption on plasma and urinary hormone (DHEA, estrogens) concentrations in premenopausal women | 30 g of ethanol daily for three menstrual cycles and no alcohol for the other three | Plasma DHEAS levels increased by 7.0% (p = 0.05) in the follicular phase Plasma estrone levels increased by 21.2% (p = 0.01) in the peri-ovulatory phase Plasma estradiol increased by 27.5% (p = 0.01), urinary estradiol increased by 31.9% (p = 0.009) in the peri-ovulatory phase At the luteal phase, urinary estrone increased by 15.2% (p = 0.05), estradiol levels increased by 21.6% (p = 0.02), and estriol levels increased by 29.1% (p = 0.03) | Results suggest a possible mechanism between alcohol consumption and risk of breast cancer.

Table C-2 Summary of results from animal studies on breast cancer

Study | Mechanism Examined | Experimental Model | Amount and Duration of Ethanol and/or Acetaldehyde Exposure | Use of Carcinogen | Results | Conclusions as Reported by Study Authors
Hilakivi-Clarke et al. 2004^92^ | Elevated levels of estrogen receptors | Rats | [underlined: Amount in study groups:] 0 g/kg ethanol vs. 16 g/kg ethanol vs. 25 g/kg ethanol [underlined: Duration of Exposure:] 12 days | Dimethylene(a)anthra cene (DMBA) | Latency to the appearance of first tumor [weeks, mean ([s.e.m)] was 9.7 (0.6) in the control, 8.4 (0.5) in the 16 g alcohol group, and 8.6 (0.5) in the 25 g alcohol group. Tumor incidence and tumor multiplicity were higher in the alcohol groups compared to control. Tumor growth rate was similar in all three groups. | Maternal alcohol intake increased offspring’s mammary tumorigenesis.
Castro et al. 2003^95^ | Biotransformation of ethanol to acetaldehyde | Rats | [underlined: Amount in study group:] 0.21M ethanol [underlined: Duration of exposure:] 1 hour | None | Biotransformation of ethanol to acetaldehyde occurred in mammary tissue microsomes. | Result could have a significant effect in some stages of the process of breast tumor promotion by ethanol.
Chhabra et al. 2000^96^ | Formation of DNA adducts | Rats | [underlined: Amount in study group:] 1.6 g/kg ethanol [underlined: Duration of exposure:] 14 days | N- nitrosodimethylamine (NDMA), 4- (methylnitrosamino)- 1-(3-pyridyl)-1- butanone (NNK) | There was a 10-fold increase in O6 - methylene adducts from NDMA in mammary gland following cotreatment with ethanol. | Nitrosamines and ethanol are contributors to mammary cancer risk and perinatal carcinogenesis.
Watabiki et al. 2000^97^ | Ethanol-induced hyperprolactinemia and/or mammary tumor virus increased by the hyperprolactinemia | Rats | [underlined: Amount in study groups:] 10% ethanol vs. 15% ethanol vs. tap water [underlined: Duration of exposure:] 25 months | None | In the ethanol-treated group, tumor occurrence was reported in 9 (45%) of the 20 rats at 8 to 24 months. There no occurrence of tumor in the control. | The murine model may be useful to study the role of ethanol in mammary tumorigenesis.
Holmberg et al. 1995^91^ | None reported | Rats | [underlined: Amount in study groups:] 1 ethanol vs. 3% ethanol [underlined: Duration of exposure:] 2 years | None | Following the administration of low amounts of ethanol, there was an increase in mammary gland fibroma, fibroadenoma or adenoma. | The finding seems not to be consistent in terms of a dose-response relationship or in their interrelation and may thus be regarded as an unspecific phenomenon.
Singletary et al. 1995^93^ | Influence on initiation and promotion stages of carcinogenesis through change in blood estrogen and progesterone | Rats | [underlined: Amount in study groups:] Diet containing ethanol at 0% calories vs. 15% calories vs. 20% calories, vs. 30% calories [underlined: Duration of exposure:] 22 days | N-methyl-N-nitrosourea (MNU) | Ethanol consumption at 15% caloric intake resulted in an increase during either the initiation or promotion stages. Ethanol consumption at 20% caloric intake resulted in increase during the promotion stage There was no effect on either stage in the group that received ethanol at 30% caloric intake. | Ethanol at specific intakes can enhance the initiation and promotion stages of MNU-induced mammary tumorigenesis. However, there was not a consistent and proportionate increase in mammary tumor development with increasing intakes of ethanol.
Singletary and McNary 1994^94^ | Effect on serum estradiol and progesterone | Rats | [underlined: Amount in study groups:] Diet containing ethanol at 0% calories vs. 20% calories, vs. 30% calories [underlined: Duration of exposure:] 35–39 days | MNU | Ethanol consumption at 20% caloric intake resulted in a 19% increase in rat mammary gland terminal-end bud (TEB) density and 49% decrease in alveolar bud (AVB) structures. Ethanol consumption at 30% caloric intake resulted in a 45% increase in rat mammary gland TEB density and 44% decrease in AVB structures. | Ethanol consumption can lead to an increase in the quantity of and the rate of cell proliferation of mammary gland terminal-end bud (TEB) structures.
Taylor et al. 1993^99^ | Suppression of cellular immunity (T cell activation and proliferation, and on natural killer [NK] cytotoxicity) | Rats | Acute ethanol exposure of 2.5–3.5 g/kg body weight 1 hour before tumor inoculation vs. chronic consumption of liquid diet containing ethanol for 2 weeks before and for 3 weeks after tumor inoculation. | Study authors only reported “Tumor inoculation” by MADB106 | Blood NK cytotoxic activity was reduced in ethanol treated rats. Number of blood large granular lymphocytes (LGL) per NK cells at 2 hours post ethanol administration dropped to 86% of control group and at 5 hours post ethanol administration: dropped to 74% of control group. | Alcohol exposure during fetal or adult life has profound immunopathological effects.
McDermott et al. 1992^101^ | The aim of the study was to test the hypothesis that dietary alcohol intake increases the incidence of experimental mammary carcinoma | Rats | [underlined: Amount in study groups:] 4.4 g/kg/day ethanol vs. tap water [underlined: Duration of exposure:] 10 days | DMBA | Mean time (days, [SD] to first tumor appearance in the alcohol group was 63 (16.3) and 67.3 (19) in the control. Mean number of tumors/animal in the alcohol group was 3.2 (2.2) and 2.9 (2.7) in the control. Tumor rate growth (mm3/day) in the alcohol group was 30.7 (17.7) and 25.5 (11.8) in the control. | This study failed to support the hypothesis that dietary alcohol intake increases the incidence of mammary carcinoma.
Hackney et al. 1992^102^ | Enhancement of the rate of mammary tumor development | Rats | [underlined: Amount in study groups:] 4 g/kg/day ethanol vs. 15 g/kg/day ethanol vs. 20 g/kg/day ethanol [underlined: Duration of exposure:] 65 weeks | None | There was no difference among study groups (p = 0.10) in development of mammary tumors. | Findings do not support the hypothesis that ethanol augments the risk of breast cancer.
Singletary and McNary 1994^104^ | Effect on mammary gland structural development, DNA synthesis, and decrease in serum progesterone | Rats | [underlined: Amount in study groups:] Diet containing ethanol at 0% vs. 15% vs. 20% vs. 25% of calories [underlined: Duration of exposure:] Experiment 1: 32 days Experiment 2: 28 days Experiment 3: 33 days | None | In experiment 1, TEB increased for rats fed ethanol at 20% and 30% caloric intake and density of AVB decreased at all ethanol concentrations. In experiment 2, TEB density of ethanol-fed rats increased 64%. In experiment 3, there was no change in serum estradiol. However, serum progesterone: decreased by 56% and 51% compared to pair-fed control and ad lib-fed control rats, respectively. | Cancer risk in humans may be proportional to both cell number and rate of cell division within a target tissue.
Singletary et al. 1991^105^ | Effect on mammary gland structural development and DNA synthesis | Rats | [underlined: Amount in study groups:] Diet containing ethanol at 0% vs. 15% vs. 20% vs. 30% of calories [underlined: Duration of exposure:] 29 days | DMBA | Rats that consumed ethanol at 10% and 20% of calories exhibited a significant increase in TEB density and a significant decrease in AVB density. Rats that consumed ethanol at 20% of total calories prior to DMBA administration exhibited a significant 54–74% increase in tumor incidence compared with rats fed the control diet. 78%, 82%, and 91% of tumor-bearing rats possessed adenocarcinomas for rats fed the diets containing 0%, 10%, and 20% of calories as ethanol, respectively. For rats fed ethanol at 30% of calories, tumor incidence was identical to that for rats fed the control diet until 12 weeks following DMBA dosing. | Specific quantities of ethanol can enhance the initiation and the promotion stages of DMBA-induced mammary tumorigenesis.
Rogers and Conner 1990^100^ | Enhancement of carcinogenesis | Rats | [underlined: Amount in study groups:] Diet providing 10% vs. 20% vs. 50% of calories as ethanol [underlined: Duration of exposure:] Exp 1: 10% of ethanol for 1 week, 20% of alcohol for 3 weeks. Exp 2: 10% of ethanol for 4 days, 20% for the remainder of the experiment. Exp 3: 10% of ethanol for 4 weeks, at the beginning of the 4th week the rats were given a single dose of 50% ethanol. | DMBA | In all experiments, there was no detectable effect on mammary tumor latency, incidence, number, weight or histology. | There was no effect of ethanol on mammary gland tumorigenesis induced by DMBA.
Grubbs et al. 1988^103^ | Enhancement of mammary cancer initiation | Rats | [underlined: Amount in study groups:] 7.0 g/kg ethanol vs. 3.5 g/kg ethanol [underlined: Duration of exposure:] DMBA group: 3 weeks MNU group: 8 weeks | DMBA MNU | Mammary cancer initiation by DMBA was increased by both dose levels of ethanol. Mammary cancer initiation by MNU was increased by high dose of ethanol. | Ethanol enhances mammary cancer initiation.
Schrauzer et al. 1979^98^ | Change in prolactin levels | Mice | [underlined: Amount in study groups:] 12% ethanol vs. table wine with an alcohol content of 11.5% [underlined: Duration of exposure:] 6 weeks | Bittner virus | Mean serum prolactin levels (ng/ml [SD]) in the alcohol group was 23 (9) and 52 (23) in the control. Tumor incidence, growth rates and latency in the alcohol group occurred in 8 animals that developed adenocarcinoma, the first at the age of 6 months (after 5 months of exposure), the last at 11 months (median: 8). The tumor incidence was 73%. Among the control, animals developed mammary tumors between 12 and 16 months of age (median: 14.2). Tumor incidence was 82% ^*^ difference in latency times was significant (p <0.001) | Long-term exposure to ethanol significantly reduced the latency period in the genesis of spontaneous mammary adenocarcinoma.

Table C-3 Summary of results from cell line studies on breast cancer

Study | Mechanism Examined | Experimental Model | Amount and Duration of Ethanol and/or Acetaldehyde Exposure | Results | Conclusions as Reported by Study Authors
Etique et al. 2009^106^ | Cross-talk between A2A Adenosine receptor (A2A AR) and the estrogen receptor-alpha | MCF-7 | [underlined: Amount in study groups:] 0.3% ethanol vs. 0.1% ethanol [underlined: Duration of exposure:] 24 hours | There was an increase in the level of progesterone receptor mRNA following 24 hours of treatment with 1uM CGS21680 (a selective agonist). Antagonist (MSX-3) induced a dose-dependent inhibition of an ethanol-induced increase in progesterone receptor expression. | Although results demonstrate cross-talk between A2A AR and estrogen receptor-alpha in the ethanol action on MCF-7 cells, the link between ethanol and A2A AR remains to be determined.
Venkata et al. 2008^115^ | Relationship between ethanol and its metabolite acetaldehyde on peroxisome proliferator-activated receptor (PPAR)alpha and PPAR(beta) transactivation | MCF-7 | [underlined: Amount in study groups:] 0 mM ethanol vs. 10 mM ethanol vs. 30 mM ethanol vs. 100 mM ethanol vs. 300 mM ethanol [underlined: Duration of exposure:] 24 hours | Over a range of ethanol concentrations up to 300mM, ethanol was able to dose dependently and significantly increase the expression of PPAR(alpha) mRNA in MCF-7 cells. Ethanol also modestly increased the mRNA for PPAR(beta) with a significant increase seen at 30 and 300mM, although not at 100mM. The increased expression for PPAR(beta) mRNA was only in the order of two-fold in contrast to the approximately sevenfold increase seen for PPAR(alpha) compared with the absence of ethanol. | There is likely to be a complex interplay in the way ethanol and/or acetaldehyde acts via the PPARs and other proteins to influence tumorigenic relevant pathways such as proliferation, resistance to apoptosis, and invasiveness.
Etique et al. 2007^68^ | Activation of the estrogen signaling pathway (cyclic AMP [cAMP]/protein kinase A [PKA]). | MCF-7 | [underlined: Amount in study groups:] 0.1% ethanol vs. 0.3% ethanol vs. 0.5% ethanol vs. 0.7% ethanol [underlined: Duration of exposure:] 24 hours | There was a significant 1.6-fold increase in progesterone receptor mRNA level for either 0.1 or 0.3% ethanol and a 1.3-fold increase in pS2 expression for a dose of 0.3%. | Ethanol treatment of MCF-7 breast cells stimulates the cAMP/PKA pathway which triggers two important events: an increase in the expression of genes with cAMP response element (CRE) in their promoter, like aromatase as well as a ligand-independent activation of estrogen receptor-alpha and transcription of target genes.
Etique et al. 2004^65^ | Stimulation of cell proliferation, estrogen receptor-alpha, and aromatase expression | MCF-7 | [underlined: Amount in study groups:] 0.0% ethanol vs. 0.1% ethanol vs. 0.3% ethanol [underlined: Duration of exposure:] Up to 6 days | Ethanol enhanced cell proliferation and clonal growth of MCF-7 cells. In the presence of 0.1% ethanol, there was a significant increase in cell proliferation (11.5%) at day 4 and it peaked at 28% at day 6. In the presence of 0.3% ethanol, there was a significant increase (11%) at day 4, and no significant change at day 6. | Study supports data suggesting that ethanol is an increased risk factor for breast cancer.
Izevbigie et al. 2002^51^ | Disruption and modulation of cell proliferation | MCF-7 | Ethanol (0.1%–10%) with or without an inhibitor of mitogen activated protein kinase 1 vs. 0.3%, 3%, and 10% ethanol for 5-, 10-, 20-, and 40-min time course experiments. | Exposure of to 65 mM (0.3% ethanol) increased incorporation of [3-H] thymidiene into MCF-7 cells by approximately two-fold over control. In contrast to the growth stimulatory effect of 0.3% ethanol, both 3% and 10% ethanol significantly inhibited cell growth. | Ethanol stimulates p44/42 mitogen-activated protein kinase’s activity and subsequent MCF-7 cell proliferation.
Przylipiak et al. 1996^110^ | Direct growth-stimulatory effect on cancer cells by enhancement of 3H-thymidine | MCF-7 | [underlined: Amount in study groups:] 0.00001% ethanol vs. 0.0001% ethanol vs. 0.001% ethanol vs. 0.01% ethanol vs. 0.1% ethanol vs. 1% ethanol vs. 10% ethanol [underlined: Duration of exposure:] 5 hours | Ethanol enhanced 3H-thymidine uptake in cultured human mammary carcinoma cell line MCF-7. The most effective concentration was 0.01% which evoked a 202% enhancement of 3H-thymidine uptake, when compared to controls. Concentrations of ethanol between 0.0001% and 10% also significantly enhanced 3H-thymidine uptake. A concentration of 0.00001% ethanol did not affect thymidine incorporation. | Ethanol appears to play a role in tumor promotion in vivo as a result of direct growth-stimulatory effect on human mammary cancer cells in vitro.
Singletary et al. 2004^107^ | Decreased capacity to remove benzo[a]pyrene diolepoxide-DNA (BPDE-DNA) adducts | MCF-10F | [underlined: Amount in study groups:] 0 mM ethanol vs. 15 mM ethanol vs. 25 mM ethanol [underlined: Duration of exposure:] 48 hours | Incubation of cells with ethanol was associated with a significant increase in prevalence of BPDE-DNA adducts compared to controls. | Ethanol-and oxidative stress- associated inhibition of carcinogen-DNA adduct removal in non-neoplastic human mammary cells may be another biological mechanism to explain the increased risk for breast cancer among women consuming alcohol.
Barnes et al. 2000^108^ | DNA adduct formation and enhancement carcinogen-induced DNA damage in target cell DNA | MCF-10F | [underlined: Amount in study groups:] Ethanol: 0, 5, 15, or 25 mM vs. Aldehyde: 0, 0.5, 2.5, or 5.0 μM [underlined: Duration of exposure:] 6 days | Exposure of cells to physiologically relevant concentrations of either ethanol or aldehyde prior to dosing with B[a]P increased adducts formation. | A possible mechanism by which alcohol intake may be enhancing breast cancer risk in humans may be through an ethanol- and aldehyde-associated increase in carcinogen-DNA adducts in the target mammary epithelial cells.
Zhu et al. 2001^109^ | Modulation of expression of ribosomal protein L7a (rpL7a) | T4TD | [underlined: Amount in study groups:] 100–400 mg/dl ethanol [underlined: Duration of exposure:] 16 days | Long-term exposure to ethanol (2 weeks) significantly reduced the transcript of rpL7a by more than 60%. | Ethanol-induced alteration of rpL7a expression may mediate the promoting effects of ethanol on breast cancer development.
Dhar and Plummer 2006^112^ | Protein expression of G-protein inwardly rectifying potassium channels (GIRK) | MDA-MB-453 | [underlined: Amount in study group:] 0.12% ethanol [underlined: Duration of exposure:] 16 hours | Transfection of GIRK1 or GIRK4 plasmids decreased gene expression in MDA-MB-453 breast cancer cells. | Functional GIRK channel exists in breast cancer cells that are involved in cellular signaling.
Singletary et al. 2001^69^ | Proliferation and intracellular content of cAMP in estrogen receptor (ER)-alpha expression | MCF-7, ZR75.1, BT-20, MDA-MB-231 | [underlined: Amount in study groups:] 0–100 mM ethanol [underlined: Duration of exposure:] Up to 10 days | Exposure of ER+ cell lines to increasing concentrations of ethanol was associated with an increase in cell proliferation. For example, ethanol added to cultures of cells at concentrations of 20–50 mM significantly stimulated proliferation of MCF-7 and ZR75.1 cells by 53–91% following 7 and 10 days of treatment, compared to controls. | Treatment with ethanol is associated with increased proliferation of two estrogen receptor-positive human breast cancer cell lines.
Zhu et al. 2001^114^ | Up-regulation of transcription of smooth muscle myosin alkali light chain (MLC 1sm) | MCF-7, T47D, MDA-MB-231 | [underlined: Amount in study groups:] 50–400 mg/dl ethanol [underlined: Duration of exposure:] 16 days | At 400 mg/dl, an ethanol-mediated increase was evident at 6 hours (55% increase), peaked at 24 hours (2.7 fold increase) following exposure. At pharmacologically relevant concentrations (e.g., 100 mg/dl), ethanol produced a significant increase of MLC 1sm expression, and progressively higher ethanol concentrations resulted in more up-regulation. | Alcohol consumption may promote the progression of breast cancer in women.
Fan et al. 2000^67^ | Stimulation of the estrogen receptor signaling | MCF-7, T47D | [underlined: Amount in study groups:] 60 mM–100 mM ethanol [underlined: Duration of exposure:] 24 hours | Alcohol partially reverses the BRCA1-mediated inhibition of estrogen receptor-alpha transcriptional activity. Alcohol down-regulates BRCA1 and up-regulates estrogen receptor-alpha expression in MCF-7 cells. | Inactivation of BRCA1 and increased estrogen-responsiveness might contribute to alcohol-induced breast cancer.
Verna and Davidson 1999^113^ | Mammary gland mucin (MUC1) upregulation | MCF-7, T84 | [underlined: Amount in study groups:] 0 mM ethanol vs. 50 mM ethanol vs. 100 mM ethanol vs. 150 mM ethanol vs. 200 mM ethanol vs. 250 mM ethanol vs. 500 mM ethanol [underlined: Duration of exposure:] Acute exposure: 24 hours Chronic exposure: up to 4 weeks | Ethanol enhanced the expression of MUC1 mRNA in a dose- and time-dependent manner in MCF-7 cells. | Ethanol regulates expression of the MUC1 gene at the transcription level which strongly suggests the existence of ethanol responsive elements in the promoter of the mucin gene.
Cyong et al. 1978^111^ | Increase cAMP levels | MM46 tumor cells | [underlined: Amount in study groups:] 0% vs. 0.1% vs. 0.5% vs. 1.0% vs. 2.5% vs. 5.0% ethanol [underlined: Duration of exposure:] 30 minutes | Dose-related increases in cAMP were observed at ethanol concentrations from 0.1% to 5.0%. | Results suggest that either tumor cell membrane, or its membrane-associated defense mechanism for detergents, may be incomplete.

## Evidence Base for Colorectal Cancer

Table C-4 Summary of results from human studies on colorectal cancer

Study | Study Design | Mechanism Examined | Amount and Duration of Ethanol and/or Acetaldehyde Exposure | Results | Conclusions as Reported by Study Authors
Basuroy et al. 2005^83^ | Case series. Mucosal biopsies from the left colon (4 forceps biopsies from visibly normal area of mucosa in each subject) were collected from subjects admitted for colonoscopy for the purpose of cancer surveillance. Authors did not report patients’ characteristics and previous alcohol exposure. | The effect of acetaldehyde on tyrosine phosphorylation, immmunofluorescence localization, and detergent-insoluble fractions of the tight junctions (TJ) and adherens junctions (AJ). | Biopsies were exposed to vapor-phase acetaldehyde, to achieve acetaldehyde concentration of 100–600 uM in the buffer bathing the tissue. Briefly, biopsies in 24-well culture plates were treated with vapor-phase acetaldehyde by placing stock acetaldehyde solution (0.1%–0.6%) in the reservoir wells and sealing the lid to the plate with tapes. 5 hours | Acetaldehyde resulted in epithelial TJ disruption by inducing tyrosine phosphorylation and dissociation from the cytoskeleton of TJ and AJ proteins. | These may have significant implications for the loss of cell-cell adhesion and increased risk for colon cancer.

Table C-5 Summary of results from animal studies on colorectal cancer

Study | Mechanism Examined | Experimental Model | Amount and Duration of Ethanol and/or Acetaldehyde Exposure | Use of Carcinogen | Results | Conclusions as Reported by Study Authors
Hayashi et al. 2007^118^ | Increased expression of cytochrome P4502E1 (CYP2E1) | Rats | [underlined: Amount in study group:] Ethanol-containing liquid diet (36% of total calories, 5% ethanol v/v) [underlined: Duration of exposure:] 36 weeks | 1,1-dimethylhydrazine (DMH) | The number of aberrant crypt foci (ACF) in colons obtained from ethanol-fed rats with DMH was 24, which was significantly more than that of the other treated rats. | The increased expression of CYP2E1 induced by chronic ethanol consumption promotes the development of DMH-induced colon cancer.
Perez-Holanda et al. 2005^73^ | Effect of ethanol consumption on experimental colon carcinogenesis using a dynamic model with concomitant administration of alcohol and dimethylhydrazine (DMH). | Rats | [underlined: Amount in study group:] Ethanol at a dose of 1.23 g/kg of body weight [underlined: Duration of exposure:] 24 weeks | DMH | Tumors developed only in DMH treated groups: 25 rats (89%) in the DMH group and 16 rats (100%) in the DMH + ethanol group. However, when excluding tumor-free animals, no differences were observed in the mean number of tumors per rat (1.67 in the DMH group compared to 1.60 in the DMH + ethanol group). | Addition of an ethanol supplement does not modify colorectal carcinogenesis using a dynamic model of tumor induction with DMH.
Pronko et al. 2002^120^ | Activities of alcohol dehydrogenase (ADH), catalase, microsomal ethanol-oxidizing system (MEOS), and aldehyde dehydrogenase (ALDH) | Rats | [underlined: Amount in study group:] Ethanol as 25% of calories [underlined: Duration of exposure:] 35 days | None | MEOS activity in the alcohol group was 149% higher compared to control group (increase not statistically significant). Effect of acute alcohol intoxication in rats consuming ethanol chronically (control vs. ethanol diet) as measured by ethanol concentrations in the colon was 9.1 (0.98) vs. 11.1 (1.52) and in the rectum was 13.6 (2.57) vs. 17.9 (2.90). Effect of acute alcohol intoxication in rats consuming ethanol chronically (control vs. ethanol diet) as measured by acetaldehyde concentrations in the colon was 7.93 (1.22) vs. 18.5 (3.94)^*^ and in the rectum: 18.1 (3.95) vs. 30.5 (7.13). ^*^p <0.05 | This mechanism can account for the local toxicity of ethanol after its chronic consumption, and relates the development of mucosal damage and compensatory hyper- regenerative processes, and possibly carcinogenesis, in the colonic and rectal mucosa of alcoholics to the effects of acetaldehyde.
Homann et al. 2000^70^ | Folate deficiency via microbial acetaldehyde production | Rats | [underlined: Amount in study group:] 3 g/kg of ethanol [underlined: Duration of exposure:] 2 weeks | None | Alcohol treatment led to very high intracolonic acetaldehyde levels (387 [185] mM). Erythrocyte, serum and small intestinal folate levels were unaffected by alcohol treatment. Alcohol administration decreased significantly colonic mucosal folate levels by 48%. | Alcohol administration leads to local folate deficiency of colonic mucosa in rats, most probably via the degradation of folate by the high levels of acetaldehyde microbially produced from ethanol.
Choi et al. 1999^124^ | DNA methylation and methylation of p53 tumor suppressor gene | Rats | [underlined: Amount in study group:] Diet containing 36% of total energy as ethanol [underlined: Duration of exposure:] 4 weeks | None | Titrated methyl uptake by colonic DNA from alcohol-fed rats was 57% less than that in control DNA (p <0.05) | Genomic undermethylation of colonic DNA was observed in the alcohol-fed rats compared to control rats.
Hakkak et al. 1996^119^ | The effects on expression of CYP2E1 and CYP2C7 | Rats | [underlined: Amount in study groups:] 8–13 g/kg/day ethanol. [underlined: Duration of exposure:] Not reported by authors. | None | CYP2E1 was found to be present in the colon and induced by ethanol. Chronic ethanol treatment increased expression of both hepatic (p <0.01) and colonic (p <0.05) CYP2E1 by three-fold. | CYP2E1 and CYP2C7 are present in the colonic tissue and are inducible by ethanol.
Simanowski et al. 1994^125^ | Effect on rectal cell proliferation (hyperregeneration) | Rats | [underlined: Amount in study group:] 36% of total calories as ethanol, with an additional acute intraperitoneal dose of 2.5 g/kg body weight [underlined: Duration of exposure:] 4 weeks | None | While age by itself did not affect colorectal cell renewal, chronic ethanol consumption stimulated rectal, but not colonic, crypt cell production rate in an age dependent manner. While no significant effect of ethanol was noted in young animals, cell proliferation was significantly enhanced in middle aged animals by 81% (95% CI: 4.1 (2.7–5.5) v 7.4 (6.0–8.7) cells/crypt/hour, p <0.001) and in old animals by 138% (95% CI: 4.5 (3.3–5.6) v 10.7 (8.9–12.4) cells/crypt/hour, p <0.001), after ethanol ingestion. There was a significant positive correlation between crypt cell production rate and acetaldehyde concentrations measured in the distal and proximal colon after an acute dose of ethanol. | Hyperregeneration of the rectal mucosa after alcohol drinking could by itself favor carcinogenesis, which is especially relevant in old age.
Niwa et al. 1991^126^ | Hyperproliferation of rectosigmoidal colon | Rats | [underlined: Amount in study groups:] 7.5% ethanol vs. 10% ethanol vs. 15% ethanol [underlined: Duration of exposure:] 414 days | Methylazoxymethanol (MAM) acetate | Incidence of colonic cancer (11/17, 85%) was higher in the group that received 10% ethanol compared to control distilled water, p = 0.04. | A relatively short-term administration of ethanol induced significant hyperproliferation of the colonic, especially rectosigmoidal colonic, mucosa.
Seitz et al. 1990^122^ | Acetaldehyde generation | Rats | [underlined: Carcinogenesis Study 1 with a duration of exposure of 15 weeks:] Liquid diet containing 36% of total calories as ethanol vs. isocaloric glucose [underlined: Carcinogenesis Study II with a duration of exposure of 3 hrs:] 2.5 ml 0.15 NaCl vs. 2.5 ml 0.15 NaCl + cyanamide (CY) vs. 2.5 ml ethanol vs. 2.5 ml ethanol + CY [underlined: Acetaldehyde Determination in Blood and Tissues:] Acute dose of ethanol (2.5 g/kg body wt) | Acetoxymethyl-methylnitrosamine (AMMN) CY | Using metaphase-arrest technique, administration of alcohol induced rectal (99.1 [2.0] vs. 9.1 [1.8] cells/crypt/hour, p <0.01), but not caecal (18.9 [1.3] vs. 22.2 [3.3]] cells/crypt/hour, p <0.05. [underlined: Mucosal concentration of acetaldehyde (nmolg/colon)]^*^ [underlined: in the] rectum was 198 (23) and 120 (23) in the caecum. These values were not affected by chronic alcohol feeding. ^*^p <0.05 | Chronic ethanol consumption can stimulate under certain experimental conditions chemically induced rectal carcinogenesis by direct mechanisms in the rectal mucosa, possibly mediated by acetaldehyde.
McGarrity et al. 1988^129^ | Changes in polyamine content | Rats | [underlined: Amount in study group:] Ethanol as 36% of total calories [underlined: Duration of exposure:] 16 weeks | DMH | DMH and DMH + ethanol groups developed 20 adenocarcinomas: with tumors located in the proximal colon (8 vs. 3), distal colon (11 vs. 114) and rectum (1 vs. 3) for the DMH and DMH + ethanol groups, respectively. No tumors developed in the control or ethanol treated groups. | Chronic ethanol consumption did not alter overall tumor formation, however consumption was reported to increase putrescine content in all 3 regions (proximal, distal colon and rectum) compared to the control liquid diet group. Increase in tissue putrescine levels may possibly reflect increased ornithine decarboxylase activity which has been shown to be increased in human colon adenocarcinomas and premalignant adenomas.
Hamilton et al. 1988^130^ | Effect on the initiation phase of carcinogenesis | Rats | [underlined: Amount in study group:] Ethanol as 33% of total calories [underlined: Duration of exposure:] 13 weeks | Azoxymethane (AOM) | After 24 hours of AOM administration, levels of DNA adducts O6-methylguanine and 7-methylguanine were reduced in the clonic mucosa of the ethanol-fed rats to 14 ±7% and 61 ±11% of controls. | Dietary ethanol during the preinduction and induction phase of the AOM model dramatically inhibits tumorigenesis.
Garzon et al. 1987^128^ | Local effect of ethanol on the colorectal mucosa | Rats | [underlined: Amount in study group:] Liquid diets containing 36% of total calories as ethanol [underlined: Duration of exposure:] 10 weeks | AMMN | Significant difference in occurrence of colorectal tumors following chronic ethanol feeding at weeks 15 (42.1 vs. 15.8, p <0.05). No significant difference was reported at weeks 18 and 21. | Chronic ethanol feeding combined with the direct acting carcinogen AMMN resulted in an earlier occurrence of colorectal tumors.
Hamilton et al. 1987^132^ | Effect on fecal bacterial flora, and colonic epithelial DNA synthesis | Rats | [underlined: Amount in study groups:] Liquid diet containing 0% ethanol vs. 9% ethanol vs. 18% ethanol as calories [underlined: Duration of exposure:] 25 weeks | AOM | Low ethanol group demonstrated a trend for higher incidence of left-sided colonic tumors compared to controls (35% vs. 15% controls, p = 0.06). The total number of tumors in the high-ethanol group compared to controls was 46% vs. 81%, p = 0.002), respectively. | Modulation of experimental colonic tumorigenesis by ethanol consumption was due to alcohol rather than other beverage constituents.
Hamilton et al. 1987^131^ | Effect on preinduction, induction, and postinduction phases of carcinogenesis | Rats | [underlined: Amount in study groups:] Liquid diet containing 11% ethanol vs. 22% ethanol vs. 33% ethanol as calories [underlined: Duration of exposure:] 13 weeks | AOM | Suppression of colonic tumorigenesis occurred in the groups with high levels of chronic dietary ethanol consumption during acclimatization and AOM administration: in the 33% and 22% diet groups, the prevalence of colonic tumors was 3% and 20% as compared with 50% in control (p <0.001 and p <0.02, respectively). | Chronic dietary ethanol effects on experimental colonic tumorigenesis with AOM are:; a. due to mechanisms affecting the preinduction and/or induction phase, including carcinogen metabolism;; b. unrelated to postinduction events such as tumor promotion and progression; and; c. dependent on ethanol dose with a threshold for inhibition of tumorigenesis which is mediated by ethanol inhibition of carcinogen metabolism.
Simanowski et al. 1986^127^ | Promotion of cell proliferation | Rats | [underlined: Amount in study group:] Liquid diet containing 36% of total calories as ethanol (6.6% v/v) [underlined: Duration of exposure:] 4 weeks | None | Cell proliferation rate was 19.1 (2.0) in the ethanol fed group vs. 9.1 (1.8) cell/crypt/hour in the carbohydrate fed group, p <0.005. Serum gastrin also was elevated in the ethanol fed group 172 (51) vs. 106 (27) pmol/l, p <0.01). | The ethanol dependent proliferative changes in the rectal mucosa are predictive of higher susceptibility of this site to carcinogenesis, supporting experimental and epidemiology data. Increased gastrin concentrations may partly explain the observed rectal hyperproliferation. Other possible causes cannot, however, be excluded.
Nelson et al. 1985^116^ | None reported by study authors | Rats | [underlined: Amount in study groups:] 95% laboratory grade ethanol diluted vs. tap water [underlined: Duration of exposure:] 19 weeks | DMH | Number of colonic tumors^*^ in the DMH group was 77 and 88 in the DMH + ethanol group. ^*^p = 0.764 | No augmentation of colonic tumor induction in rats supplemented by dietary ethanol was seen.
Seitz et al. 1985^123^ | Generation of acetaldehyde | Rats | [underlined: Amount in study groups:] Ethanol given as 36% of total calories; ethanol concentration of alcohol diet was 6.6% (v/v) vs. isocaloric carbohydrates [underlined: Duration of exposure:] 4 weeks | DMH | There was a 2.8 fold increase in rectal tumors on the ethanol fed rats compared to controls (p <0.02). All large intestinal tumors were located in the rectum in 47% of ethanol fed rats vs. 27% in controls. | The observed increase of ADH activity in the distal colorectum after chronic ethanol feeding may be of relevance with respect to the cocarcinogenic effect of ethanol in the rectum.
Howarth et al. 1984^117^ | None reported by study authors | Rats | [underlined: Amount in study groups:] High-fat diet vs. Beer vs. Alcohol (4.8% v/v) [underlined: Duration of exposure:] 20 weeks | DMH | Alcohol did not affect the incidence of intestinal cancers. The shift of mean tumor distance toward the anus was similar in ethanol drinkers (0.61 [0.33] to 0.33 [0.23], p <0.05). | Alcohol had no effect in our syngeneic model of DMH-induced colorectal cancer, while a high-fat diet had a potent cocarcinogenic effect.
Roy et al. 2002^121^ | Effect on cell proliferation, apoptosis, and formation of mutagenic malondialdehyde-acetaldehyde (MAA) | Mice | [underlined: Amount in study group:] Ethanol supplementation in the drinking water (15% alternating with 20% on a daily basis) [underlined: Duration of exposure:] 10 weeks | None | Ethanol supplementation resulted in a significant increase in tumor number (135± 35%, p = 0.027 vs. control). The induction of tumorigenesis by ethanol was most dramatic in the distal small bowel (167± 56%, p = 0.001). | Ethanol consumption is a risk factor for colorectal cancer.

Table C-6 Summary of results from cell line studies on colorectal cancer

Study | Mechanism Examined | Experimental Model | Amount and Duration of Ethanol and/or Acetaldehyde Exposure | Results | Conclusions as Reported by Study Authors
Lemos et al. 2007^140^ | Modulation of folate uptake | Caco-2 | [underlined: Amount in study group:] 12% alcohol [underlined: Duration of exposure:] Not reported | Ethanol had an acute inhibitory effect on both 3H-folic acid and 3H-methotrexate uptake. | Alcohol inhibited 3H-folic acid uptake in Caco-2 cells.
Rodriguez et al. 2004^75^ | Increase in tumor necrosis factor-alpha receptor-1 (TNF-R1) levels | Caco-2 | [underlined: Amount in study groups:] 25 mM ethanol vs. 50 mM ethanol vs. 100 mM ethanol [underlined: Duration of exposure:] 48 hours | Caco-2 cells showed a significant 80% increase in TNF-R1 levels at 200 mM ethanol (p <0.05). | Exposure of intestinal cells to pharmacologic concentrations of ethanol increases TNF-R1 levels and may augment TNF-alpha- mediated cell injury.
Asai et al. 2003^134^ | Intestinal epithelial cell death induced by acute, low concentrations of ethanol | Caco-2 | [underlined: Amount in study groups:] 0% ethanol vs. 5% ethanol vs. 10% ethanol [underlined: Duration of exposure:] 3 hours | Treatment with 5% and 10% ethanol for 3 hours led to a gradual increase in phosphatidylserine (PS) externalization. Caspase- mediated CK18 was significantly enhanced as early as 1 hour after 10% ethanol incubation, while DNA fragmentation was detected from 2 hours onwards. | Apoptotic cell death in confluent Caco-2 cells was induced by acute and low concentrations of ethanol. These results suggest that clinically achievable doses of ethanol impair intestinal barrier function by induction of apoptosis in intestinal epithelial cells.
Tong et al. 1999^74^ | Induction of epidermal growth factor receptor (EGFR) expression and mitogenesis | Caco-2 | [underlined: Amount in study group:] 0.22 mM of ethanol [underlined: Duration of exposure:] 24 hours | Alcohol affects proliferation of Caco-2 cells, elevates EGFR expression and raises cyclin D1 mRNA and protein expression. | Low blood levels of alcohol may stimulate in vivo proliferation of colonocytes by elevating transcription of a growth factor receptor as well as modifying expression of a cell cycle regulator.
Koivisto and Salaspuro 1998^136^ | Effect of acetaldehyde alone or in combination with ethanol on cell proliferation rate | Caco-2 | [underlined: Study 1:] Acute exposure: cells were exposed to acetaldehyde and/or ethanol for 72 hours. [underlined: Study 2:] Chronic exposure: cells were grown in the presence of acetaldehyde and/or ethanol for five passages with daily change of media. | No significant differences were observed between the four groups in the cytotoxic studies (control vs. 100 mM ethanol vs. 500 uM acetaldehyde vs. 1,000 uM acetaldehyde) suggesting that a 72 hour treatment with 500 or 1,000 uM acetaldehyde, or 100 mM ethanol does not have cytotoxic effects on these cells. In the proliferation studies, the acute effect of acetaldehyde on the proliferation rate of Caco-2 cells was strongly inhibitory. The duplication time of Caco-2 cells was also significantly increased by acute exposure to 100 mM ethanol. Concomitant presence of ethanol did not, however, significantly alter the proliferation rate of acetaldehyde-treated cells. 5-week treatment with 500 uM acetaldehyde, both alone and in combination with 100 mM ethanol, significantly decreased cell duplication time as compared with control. A 5-week treatment with 100 mM alone did not have any significant effect on cell proliferation rate. Acetaldehyde decreased the adhesion of Caco-2 cells to both collagens 1 & IV in the cell adhesion studies. | Ethanol-driven or even endogenous acetaldehyde contributes to the initial steps of colonic carcinogenesis and has an effect on later tumor development.
Koivisto and Salaspuro 1997^137^ | Effect of acetaldehyde on brush border enzyme activities | Caco-2 | [underlined: Amount in study groups:] 500 uM acetaldehyde vs. 500 uM acetaldehyde + 100 mM ethanol vs. 1,000 uM acetaldehyde + 100 mM ethanol vs. 100 mM ethanol [underlined: Duration of exposure:] 13 days | Ethanol alone significantly increased the specific activities of sucrase and maltase, but no significant effect on lactase activity. Only ethanol increased alkaline phosphatase activity. Control cells, as well as cells grown in the presence of 100 mM ethanol alone or 500 uM acetaldehyde, showed a typical pattern of dome formation, with a sharp increase in the number of domes a few days after the confluency, followed by a rapid decrease and plateau. Cells grown in presence of both 100 mM ethanol and 1,000 uM acateladehyde showed significantly fewer domes 4 and 7 days after the confluency than control cells. The acetaldehyde dehydrogenase (ALDH) activity of Caco-2 cells, measured using 200 uM acetaldehyde as substrate was quite similar to that of normal colonic mucosa. | Acetaldehyde decreases the activities of some, but not all, brush border enzymes in Caco-2 cells.
Vaculova et al. 2004^133^ | Modulation of the tumor necrosis factor (TNF)-related apoptosis-inducing ligand (TRAIL)-induced apoptosis | HT-29 | [underlined: Experiment 1:] 4% ethanol alone or in combination for 4 or 24 h in the medium with 5% of fetal calf serum (FCS). [underlined: Experiment 2:] Using ethanol (0.1–6%) alone, the cells were treated for 48 hours. | There was only a limited cytotoxicity of TRAIL (100 ng/ml) in HT-29 cells. After 24-hour-treatment, the cell viability was 82%. However, when TRAIL was combined with ethanol, only 40% of cells remained viable. There was no significant changes in ethanol-treated cells and about two-fold enhancement of the number of cells with decreased MMP after TRAIL treatment (4 hours) compared to control were detected. | Ethanol acts as a potent agent, sensitizing colon cancer cells to TRAIL-induced apoptosis.
Blasiak et al. 2000^135^ | Formation of crosslinks with DNA | Colonic mucosa (CM) cells | [underlined: Single exposure study:] CM cells were exposed to ethanol at 10 mm vs. acetaldehyde at 100 mm for 1 hour. [underlined: Combined exposure study:] In combined exposure, the cells were subsequently exposed to ethanol and acetaldehyde at all combinations of the concentrations of the agents for 1 hour | Ethanol caused DNA strand breaks. The CM cells exposed to ethanol at 100 mM were able to remove DNA damage within time period shorter than 2 hours. | Alcohol consumption may lead to the damage to DNA of gastrointestinal tract, which in turn can directly or indirectly contribute to the appearance and development of cancers of this organ.
Papavassiliou et al. 1994^139^ | Modulation of human leukocyte antigen (HLA) class I gene expression | HT-29, SW-1116, HCT-15 | [underlined: Amount in study group:] 100% ethanol [underlined: Duration of exposure:] 48 hours | Ethanol had no effect on the expression of HLA class 1 antigens in human colon adenocarcinoma cell lines. Ethanol (1.7 x 10^−10^ M to 1.7 x 10^−1^ M), had no effect on the expression of HLA class 1 antigens on these colonocytes, corresponding mRNA levels, or the expression of HLA constructs. | These findings do not support the hypothesis that ethanol may modulate the expression of HLA class 1 genes in human colon cancer cells.
Malagolini et al. 1994^138^ | Differentiation of intestinal cells | Caco-2, HT-29 | [underlined: Amount in study groups:] 0 mM ethanol vs. 50 mM ethanol vs. 100 mM ethanol vs. 200 mM ethanol [underlined: Duration of exposure:] 7 days | The addition of ethanol in the culture medium resulted in a significant increment of sucrase and alpha 2, 6-sialyltransferase activities in all cell lines, as well as the beta 1, 4-N-acetylgalactosaminyl-transferase activity in the Caco-2 cells and alkaline phosphatase activity in HT-29 cells. | Ethanol in vitro affects the differentiation of intestinal cells along the enterocytic lineage.

Table C-7 Summary of results from combination study (animal, cell line) on colorectal cancer

Study | Mechanism Examined | Experimental Model | Amount and Duration of Ethanol and/or Acetaldehyde Exposure | Use of Carcinogen | Results | Conclusions as Reported by Study Authors
Pannequin et al. 2007^141^ | Accumulation of phosphatidylethanol resulting in a signal change in intestinal cell proliferation | Mice, Caco-2 | [underlined: Animal study:] 2 mol/L (10%) ethanol for 4 months. [underlined: Cell line study:] 10 mmol/L of ethanol or 0.5 mmol/L of acetaldehyde once daily for 48 hours. | None | Chronic exposure to low doses of ethanol (10 mmol/L) induces an increase of maximal intestinal cell density. | The disruption of cellular signals might facilitate the stimulatory role of ethanol metabolites such as acetaldehyde on the proliferation of cells within intestinal crypts, thereby participating in the well-established cocarcinogenic role of alcohol consumption in the colon.