# Sample Data Abstraction Forms

[underlined: Level 1] [underlined: – Abstract Review:] At this review level abstracts were examined to determine if a document should be retrieved for further review. Checking the inclusion boxes in the form automatically led to retrieval of the full article. All documents selected for inclusion at this level fell to the next level for evaluation.

[underlined: Level 2] [underlined: – Full Document Review]: At this level we made the final determination as to whether the document was to be excluded or included in the report. The reason for exclusion was noted in a separate box on the form. All documents selected for inclusion at this level fell to the next level for evaluation.

[underlined: Level 3] [underlined: – Background Document Review]: At this level we determined if the document will appear in the Background section of the report or in the Evidence section of the report. If the document was to be used as background material this form was used to indicate which area in the Background section the document belonged. All documents selected for inclusion in the evidence report at this level fell to the next level for evaluation.

[underlined: Level 4] [underlined: – Evidence Base Document Review]: Only documents that were used in the evidence report appeared at this level. Information recorded at this level was used to organize the documents into specific areas of study depending on study design.

Table B-1 Data abstraction and data management

Document ID#: internal ECRI Institute ID number
Article Citation
Country where study was completed
Year in which the study was performed
Experimental Model: type of animal model or cell line
Primary Mechanism examined: mechanism being tested for relationship between alcohol intake and cancer risk
Secondary Mechanism examined: for studies that explore multiple mechanisms
Amount of Alcohol Exposure: levels of alcohol exposure depending on the design of the experiment and the experimental model
Mode of Administration: mode of administration of alcohol depending on the design of the experiment and the experimental model
Duration of Alcohol Exposure: duration of alcohol exposure depending on the design of the experiment and the experimental model
Use of a Carcinogen: the carcinogenic agent, if any, being examined in the study along with alcohol
Use of other non-carcinogen agents: nutritional or other interventional agents utilized to show the relationship between alcohol intake and cancer risk
Description of subject characteristics in human studies: age, male/female ratio, smoking, comorbidities, race/ethnicity, alcoholism
Study design: explains the type of study design
Duration of the study
Direct or Indirect Association: explains evidence of carcinogenesis
Results for Intermediate Outcomes: usually molecular, biochemical, or histological outcomes which may be indicative of a direct or indirect relationship between alcohol intake and cancer risk
Results for Clinical Outcomes: typically broader organ measurements that correlate to a direct or indirect relationship between alcohol intake and cancer risk
Results for Patient Oriented Outcomes: entries in this column are only for human studies
Conclusions: did the study present evidence for or against the proposed mechanism