# Exact Search Strings

## Electronic Database Searches

The following databases have been searched for relevant information:

Name | Date Limits | Platform/Provider
Cancerlit | 1935 - September 18, 2009 | www.pubmed.gov
ClinicalTrials.gov | Searched February 1, 2009 | www.clinicaltrials.gov
The Cochrane Central Register of Controlled Trials (CENTRAL) | Through 2010, Issue 1 | www.thecochranelibrary.com
The Cochrane Database of Methodology Reviews (Methodology Reviews) | Through 2010, Issue 1 | www.thecochranelibrary.com
The Cochrane Database of Systematic Reviews (Cochrane Reviews) | Through 2010, Issue 1 | www.thecochranelibrary.com
Database of Abstracts of Reviews of Effects (DARE) | Through 2010, Issue 1 | www.thecochranelibrary.com
EMBASE (Excerpta Medica) | 1980 through May 3, 2010 | OVID
Health Technology Assessment Database (HTA) | Through 2010, Issue 1 | www.thecochranelibrary.com
MEDLINE | 1965 through May 3, 2010 | OVID
U.K. National Health Service Economic Evaluation Database (NHS EED) | Through 2010, Issue 1 | www.thecochranelibrary.com

## Medical Subject Headings (MeSH), EMTREE, PsycINFO and Keywords

### Conventions

OVID

$ = truncation character (wildcard)

exp = “explodes” controlled vocabulary term (e.g., expands search to all more specific related terms in the vocabulary’s hierarchy)

/ = limit controlled vocabulary heading

.fs. = floating subheading

.hw. = limit to heading word

.md. = type of methodology (PsycINFO)

.mp. = combined search fields (default if no fields are specified)

.pt. = publication type

.ti. = limit to title

.tw. = limit to title and abstract fields

PubMed

[mh] = MeSH heading

[majr] = MeSH heading designated as major topic

[pt] = publication type

[sb] = subset of PubMed database (PreMEDLINE, Systematic, OldMEDLINE)

[sh] = MeSH subheading (qualifiers used in conjunction with MeSH headings)

[tiab] = keyword in title or abstract

Topic-specific search terms – alphabetical listing

Concept | Controlled Vocabulary | Keywords
Adrenal | Adrenal.hw. exp Adrenal gland/ exp Adrenal glands/ exp Endocrine system/ | Adrenal Aldosterone Endocrine gland$ Primary hyperaldosteroneism
Alcohol | Alcohol Alcohol abstinence Alcohol drinking exp Alcohol-related disorders exp Alcoholic beverage exp Alcoholic beverages Alcohol metabolism Drinking behavior Ethanol Feeding behavior Food habits Temperance | Abstinence Alcohol$ Beer Brandy Cocktail$ EtOH Gin Liqueur$ Liquor$ Mixed drink$ Schnapps Spirits Vodka
Biochemical Processes | Exp biochemical processes/
Breast cancer | exp breast cancer Breast carcinoma exp Breast diseases exp Breast neoplasms | Breast$ Cancer$ Carcinoma$ Lesion$ Lump$ Mammar$ Tumo?r$
Colorectal cancer | Adenomatous polyp Colorectal cancer Colorectal carcinoma Exp colorectal neoplasms | Cancer$ Carcinoma$ Colon$ Colorectal Lesion$ Polyp$ Rectal Rectum Tumo?r$
Experimental neoplasms | Experimental neoplasm/ exp Neoplasms, experimental/
Hypothalamic-hypophyseal system | Hypothalamo-hypophyseal system Hypothalamus hypophysis system Pituitary gland | Hypothalamus hypophysis gonad system
Microbes | Achlorhydria/ Bacteria, aerobic Candida albicans Colon flora Intestine flora Microbial growth Microbiology.fs. microorganism | Bacteria Bacteriocolonic Flora Microb$ Microflora Yeast$
Oncogenesis | Breast carcinogenesis Chemical carcinogenesis Colorectal carcinogenesis Malignant neoplastic disease exp neoplastic processes exp Oncogenesis and malignant transformation | Carcinogenesis Oncogenesis Tumorigenesis Tumorigenic effect
Potential mechanisms | 5,10 methlyenetetrahydrofolate reductase (FADH2) Acetaldehyde Alcohol dehydrogenase Aldehyde dehydrogenase ALDH2 Apoptosis Calcium signaling Cell cycle Cell cycle regulation Cell division Cell membrane permeability Cell nucleus Cell proliferation Cyclin dependent kinase 2 cyp2E1 Cytochrome p-450 enzyme system cytochrome p450 17 cytochrome p450 1A1 cytochrome p450 1A2 cytochrome P450 1B1 cytochrome P-450 CYP1A1 cytochrome P-450 CYP1A2 cytochrome P-450 CYP2B1 cytochrome P-450 CYP2D6 cytochrome P-450 CYP2E1 cytochrome P-450 CYP3A Deamination DNA adducts exp DNA-binding proteins DNA damage Down regulation Estrogen activity Estrogen metabolism Estrogen receptor, alpha Estrogen receptor beta Fas antigen Folate metabolism exp Folic acid Folic acid Folic acid deficiency Gene control exp Gene expression regulation Gene function Gene mutation Genetic code Genetic polymorphism Genetic variability Growth regulation modulation hydroxylation MAP kinase signaling system Metabolism.fs. Methionine synthase Mitochondria exp Mitogen-activated kinases Mitogen activated protein kinase NF-kappa B Oxidative phosphorylation Oxidative stress p16 protein human.sn. Polymorphism, genetic Protein expression Protein p16 Proto oncogene Exp reactive nitrogen species Reactive oxygen metabolite Exp Reactive oxygen species Receptor cross talk Receptor upregulation exp Receptors, estrogen exp Receptors, retinoic acid Retinoid Retinoic acid receptor beta exp Signal transduction exp Transferases Tretinoin | Acetaldehyde$ MAPK MAPKs NFkappaB Proto-oncogene Reactive oxygen

EMBASE/MEDLINE

English language, remove overlap

Set Number | Concept | Search Statement
1 | Alcohol | Alcohol drinking/or exp alcohol-related disorders/or alcohol metabolism/
2 | | exp alcoholic beverage/or exp alcoholic beverages/or alcohol/or ethanol/or beer or wine or alcohol$ or brandy$ or gin or vodka or schnapps or EtOH or liquor$ or liqueur$ or spirits or mixed drink$ or cocktail$
3 | | Drinking behavior/or food habits/or feeding behavior/or temperance/or alcohol abstinence/or abstinence
4 | Combine sets | or/1–3
| Oncogenesis
5 | Carcinogenesis | Exp neoplastic processes/or exp oncogenesis and malignant transformation/or malignant neoplastic disease/or breast carcinogenesis/or colorectal carcinogenesis/or chemical carcinogenesis/or exp neoplasms, experimental/or experimental neoplasms
6 | | Carcinogenesis or oncogenesis or tumorigenesis or tumorigenic effect
7 | Combine sets | or/5–6
| Potential mechanisms
8 | | Proto oncogene/or proto-oncogene or exp DNA-binding proteins/
9 | | Metabolism.fs. or deamination/
10 | Signaling | Receptor cross-talk/or exp signal transduction/or calcium signaling/or exp gene expression regulation/or down regulation/or protein expression/or receptor upregulation/or growth regulation modulation/
11 | Estrogen | Estrogen receptor, alpha/or exp receptors, estrogen/or estrogen activity/or estrogen metabolism/or estrogen receptor beta/
12 | MAPK | Exp mitogen-activated kinases/or MAP kinase signaling system/or mitogen activated protein kinase/or MAPK or MAPKs
13 | Cytochrome P-450 | Cytochrome p-450 enzyme system/or cyp2E1/or cytochrome P450 17/or cytochrome P450 1A1/or cytochrome P450 1A2/or cytochrome P450 1B1/or cytochrome P-450 CYP1A1/or cytochrome P-450 CYP1A2/or cytochrome P-450 CYP2B1/or cytochrome P-450 CYP2D6/or cytochrome P-450 CYP2E1/or cytochrome P-450 CYP3A/
14 | Dehydrogenases | Alcohol dehydrogenase/or aldehyde dehydrogenase/or ALDH2/or acetaldehyde$
15 | Methylation | exp Folic acid/or Folic acid/or folic acid deficiency/or folate metabolism/
16 | | DNA methylation/or RNA methylation/or DNA hypermethylation/or DNA hypomethylation/or methylation
17 | | Methionine synthase/
18 | | Cyclin dependent kinase 2/or Fas antigen/or 5,10 methlyenetetrahydrofolate reductase FADH2/or Protein p16/or p16 protein human.nm.
19 | Cells | Apoptosis/or cell division/or cell proliferation/or cell cycle/or cell cycle arrest/or cell cycle regulation/or cell membrane permeability/or cell nucleus/
20 | Misc. genetic concepts | Gene control/or gene function/or gene mutation/or genetic code/or genetic polymorphism/or genetic variability/or polymorphism, genetic/
21 | DNA | DNA adducts/or DNA damage/or mitochondria/or exp DNA-binding proteins/
22 | Oxidation | Reactive oxygen metabolite/or oxidative stress/or hydroxylation/or exp reactive oxygen species/or oxidative phosphorylation/or reactive oxygen or exp reactive nitrogen species/
23 | Retinoic acid | Retinoid/or retinoic acid receptor beta/or exp receptors, retinoic acid/or tretinoin/
24 | | NF-kappa B/or NFkappaB
25 | | Exp transferases/
26 | Acetaldehyde | Exp acetaldehyde/or acetaldehyde$
27 | Biochemical processes (includes DNA repair) | Exp biochemical processes/
28 | Adrenal | Exp Adrenal gland/or exp adrenal glands/or adrenal.hw. or adrenal.tw. or aldosterone or primary hyperaldosteroneism or exp endocrine system/or endocrine gland$
29 | Hypothalamic | Hypothalamo-hypophyseal system/or hypothalamus hypophysis system/or Hypothalamus hypophysis gonad system or pituitary gland/
30 | Microbial | Microflora or microbiology.fs. or microb$.ti. or achlorhydria/or bacteria, aerobic/or candida albicans/or colon flora/or intestine flora/or microbial growth/or microorganism/or bacteria or bacteriocolonic or flora or Microflora or yeast$
31 | Combine sets (mechanisms) | or/8–30
32 | Breast cancer | exp Breast neoplasms/or exp breast diseases/or exp breast cancer/or breast carcinoma/
33 | | (breast or mammar$) and (tumo?r$ or lesion$ or cancer$ or carcinoma$ or lump$)
34 | Combine sets (breast cancer) | or/32 –33
35 | Colorectal cancer | Exp colorectal neoplasms/or adenomatous polyp/or colorectal cancer/or colorectal carcinoma/
36 | | (colon$ or rectal or rectum or colorectal) and (tumo?r$ or lesion$ or cancer$ or carcinoma$ or polyp$)
37 | Combine sets (colorectal cancer) | or/35–36
38 | Combine sets Alcohol, oncogenesis & breast cancer | 4 and 7 and 34
39 | Combine sets Alcohol, mechanisms & breast cancer | 4 and 31 and 34
40 | Combine sets Alcohol, oncogenesis & colorectal cancer | 4 and 7 and 37
41 | Combine sets Alcohol, mechanisms & colorectal cancer | 4 and 31 and 37
42 | Combine sets | 38 or 39 or 40 or 41
43 | Limit to English | 42 and English
44 | Non-English | 42 not 43
45 | Eliminate overlap | Remove duplicates from 43