# Appendixes

Appendix A Exact Search Strings

Appendix B Sample Data Abstraction Forms

Appendix C Evidence Tables

Appendix D List of Excluded Studies

Appendix E Peer Reviewers