# Acknowledgments

The Evidence-based Practice Center would like to thank Eileen Erinoff, MSLIS, and Helen Dunn for providing literature retrieval and documentation management support; Lydia Dharia and Kitty Donahue for their assistance with the final preparations of the report; Mary White, Sc.D., M.P.H., of the Centers for Disease Control and Prevention; and Stephanie Chang, M.D., M.P.H., of the Agency for Healthcare Research and Quality, for advice as our Task Order Officer.