# List of Acronyms/Abbreviations

ADH: alcohol dehydrogenase
ALDH: aldehyde dehydrogenase
AJ: adherens junctions
AMMN: acetoxymethyl-methylnitrosamine
AOM: azoxymethane
BPDE: benzo[a]pyrene diolepoxide
BRCA1: breast cancer type 1
cAMP: cyclic adenosine monophosphate
CM: colonic mucosa
CY: cyanamide
CYP2E1: cytochromes P450 2E1
DHEA: dehydroepiandrosterone
DHEAS: DHEA sulfate
DMBA: dimethylene (a) anthracene
DMH: 1,1-dimethylhydrazine
DNA: deoxyribonucleic acid
EGFR: epidermal growth factor receptor
ER: estrogen receptor
ERT: estrogen replacement therapy
FCS: fetal calf serum
HLA: human leukocyte antigen
H_2_O_2_: hydrogen peroxide
H_2_O: water
JACC: Japan Collaborative Cohort Study
JPHC: Japan Public Health Center-based Prospective Study
MAA: mutagenic malondialdehyde-acetaldehyde
MAM: methylazoxymethanol
MEOS: microsomal ethanol-oxidizing system
MLC: myosin alkali light chain
MNU: N-methyl-N-nitrosurea
NAD: nicotinamide adenine dinucleotide
NADH: reduced nicotinamide adenine dinucleotide
NMDA: N-nitrosodimethylamine
NNK: 4-methylnitrosoamino-1-3-pyridyl-1-butanone
PK: protein kinase
PPAR: peroxisome proliferator-activated receptor
PR: progesterone receptor
ROS: reactive oxygen species
rp: ribosomal protein
SAM: s-adenosylmethionine
TNF: tumor necrosis factor
TJ: tight junctions