# References and Included Studies

1 Newman W, Payne K, Tricker K, Roberts S, Fargher E, Pushpakom S, Alder J, Sidgwick G, Payne D, Elliott R, et al. A pragmatic randomised controlled trial of thiopurine methyltransferase (TPMT) genotyping in the managment of patients, prior to azathioprine treatment: The TARGET study[Draft]. 2010. Unpublished work.
2 Perillo M, Hannan M, Lemberg D. Advanced diagnostic imaging of adults with neck or low back pain: a seed algorithm. Topics in Clinical Chiropractic. 03. 1997;4(1):9-14.
3 Scerri L. Azathioprine in dermatological practice. An overview with special emphasis on its use in non-bullous inflammatory dermatoses. Adv Experiment Med Biol. 1999;455:343-8.
4 Parfrey PS, Hutchinson TA, Lowry RP, et al. The role of azathioprine reduction in late renal allograft failure. Transplantation. 02. 1985;39(2):147-51. [pmid: 3881853].
5 Gheith OA, Bakr MA, Fouda MA, et al. Prospective randomized study of azathioprine vs cyclosporine based therapy in primary haplo-identical living-donor kidney transplantation: 20-year experience. Clin Exp Nephrol. 06. 2007;11(2):151-5. [pmid: 17593515].
6 Vora A, Mitchell CD, Lennard L, et al. Toxicity and efficacy of 6-thioguanine versus 6-mercaptopurine in childhood lymphoblastic leukaemia: a randomised trial. Lancet. 10. 14. 2006;368(9544):1339-48. [pmid: 17046466].
7 Eklund BI, Moberg M, Bergquist J, et al. Divergent activities of human glutathione transferases in the bioactivation of azathioprine. Molecular Pharmacol. 08. 2006;70(2):747-54.
8 Swann PF, Waters TR, Moulton DC, et al. Role of postreplicative DNA mismatch repair in the cytotoxic action of thioguanine. Science. 08. 23. 1996;273(5278):1109-11. [pmid: 8688098].
9 Elion GB. The purine path to chemotherapy. Science. 04. 7. 1989;244(4900):41-7. [pmid: 2649979].
10 Tiede I, Fritz G, Strand S, et al. CD28-dependent Rac1 activation is the molecular target of azathioprine in primary human CD4+ T lymphocytes. J Clin Invest. 04. 2003;111(8):1133-45. [pmid: 12697733].
11 Krynetski EY, Fessing MY, Yates CR, et al. Promoter and intronic sequences of the human thiopurine S-methyltransferase (TPMT) gene isolated from a human PAC1 genomic library. Pharmaceutical Research. 12. 1997;14(12):1672-8. [pmid: 9453052].
12 Seki T, Tanaka T, Nakamura Y. Genomic structure and multiple single-nucleotide polymorphisms (SNPs) of the thiopurine S-methyltransferase (TPMT) gene. J Hum Genet. 2000;45(5):299-302. [pmid: 11043513].
13 Lee D, Szumlanski C, Houtman J, et al. Thiopurine methyltransferase pharmacogenetics. Cloning of human liver cDNA and a processed pseudogene on human chromosome 18q21.1. Drug Metabol Dispos. 03. 1995;23(3):398-405.
14 Ujiie S, Sasaki T, Mizugaki M, et al. Functional characterization of 23 allelic variants of thiopurine S-methyltransferase gene (TPMT*2 - *24). Pharmacogenet Genomics. 10. 2008;18(10):887-93. [pmid: 18708949].
15 Gisbert JP, Gomollon F. Thiopurine-induced myelotoxicity in patients with inflammatory bowel disease: A Review. Am J Gastroenterol. 2008;103(7):1783-800. [pmid: 18557712].
16 Meggitt SJ, Reynolds NJ. Azathioprine for atopic dermatitis. [Review] [39 refs]. Clin Exp Dermatol. 07. 2001;26(5):369-75. [pmid: 11488818].
17 Ameyaw MM, Collie-Duguid ES, Powrie RH, et al. Thiopurine methyltransferase alleles in British and Ghanaian populations. Hum Molecul Genet. 02. 1999;8(2):367-70.
18 Collie-Duguid ES, Pritchard SC, Powrie RH, et al. The frequency and distribution of thiopurine methyltransferase alleles in Caucasian and Asian populations. Pharmacogenetics. 02. 1999;9(1):37-42. [pmid: 10208641].
19 Efrati E, Adler L, Krivoy N, et al. Distribution of TPMT risk alleles for thioupurine toxicity in the Israeli population. Eur J Clin Pharmacol. 03. 2009;65(3):257-62. [pmid: 19048244].
20 Weyer N, Kroplin T, Fricke L, et al. Human thiopurine S-methyltransferase activity in uremia and after renal transplantation. Eur J Clin Pharmacol. 05. 2001;57(2):129-36. [pmid: 11417444].
21 Kurzawski M, Gawronska-Szklarz B, Drozdzik M. Frequency distribution of thiopurine S-methyltransferase alleles in a polish population. Ther Drug Monit. 10. 2004;26(5):541-5. [pmid: 15385838].
22 McLeod HL, Pritchard SC, Githang'a J, et al. Ethnic differences in thiopurine methyltransferase pharmacogenetics: evidence for allele specificity in Caucasian and Kenyan individuals. Pharmacogenetics. 12. 1999;9(6):773-6. [pmid: 10634140].
23 Engen RM, Marsh S, Van Booven DJ, et al. Ethnic differences in pharmacogenetically relevant genes. [Review] [120 refs]. Curr Drug Targets. 12. 2006;7(12):1641-8. [pmid: 17168839].
24 Wang L, Pelleymounter L, Weinshilboum R, et al. Very important pharmacogene summary: thiopurine S-methyltransferase. Pharmacogenet Genomics. 06. 2010;20(6):401-5. [pmid: 20154640].
25 Salavaggione OE, Wang L, Wiepert M, et al. Thiopurine S-methyltransferase pharmacogenetics: variant allele functional and comparative genomics. Pharmacogenet Genomics. 11. 2005;15(11):801-15. [pmid: 16220112].
26 Hamdan-Khalil R, Allorge D, Lo-Guidice JM, et al. In vitro characterization of four novel nonfunctional variants of the thiopurine S-methyltransferase. Biochem Biophys Res Commun. 10. 3. 2003;309(4):1005-10. [pmid: 13679074].
27 Kham SK, Soh CK, Aw DC, et al. TPMT*26 (208F-->L), a novel mutation detected in a Chinese. Br J Clin Pharmacol. 07. 2009;68(1):120-3. [pmid: 19660010].
28 Feng Q, Vannaprasaht S, Peng Y, et al. Thiopurine S-methyltransferase pharmacogenetics: Functional characterization of a novel rapidly degraded variant allozyme. Biochem Pharmacol. 2010;79(7):1053-61. [pmid: 19945438].
29 Sasaki T, Goto E, Konno Y, et al. Three novel single nucleotide polymorphisms of the human thiopurine S-methyltransferase gene in Japanese individuals. Drug Metab Pharmacokinet. 08. 2006;21(4):332-6. [pmid: 16946561].
30 Anstey AV, Wakelin S, Reynolds NJ, et al. Guidelines for prescribing azathioprine in dermatology. [Review] [54 refs]. Br J Dermatol. 12. 2004;151(6):1123-32. [pmid: 15606506].
31 Lichtenstein GR, Abreu MT, Cohen R, et al. American Gastroenterological Association Institute medical position statement on corticosteroids, immunomodulators, and infliximab in inflammatory bowel disease. Gastroenterol. 03. 2006;130(3):935-9.
32 U.S.Food and Drug Administration - Center for Drug Evaluation and Research. Overview: Imuran [website]. http://www.accessdata.fda.gov/scripts/cder/drugsatfda/index.cfm.2009. Last accessed: Dec 15 2009.
33 Sampson M, McGowan J, Cogo E, et al. An evidence-based practice guideline for the peer review of electronic search strategies. J Clin Epidemiol. 09. 2009;62(9):944-52. [pmid: 19230612].
34 EPPI-Centre Software. EPPI-Reviewer 30: analysis and management of data for research synthesis [computer program]. Social Science Research Unit, Institute of Education. 2006.
35 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 11. 10. 2003;3:25. [pmid: 14606960].
36 Organization for Economic Co-Operation and Development. Purchasing Power Parities (PPP) [website]. Available from: http://www.oecd.org/department/0,3355,en_2649_34357_1_1_1_1_1,00.html. 2009. [updated 2009; cited 2009 May 15].
37 U S Bureau of Labor Statistics. Databases, tables & calculators by subject [website]. Available from: http://www.bls.gov/data/#prices. 2009. [updated 2009; cited 2009 May 15].
38 Minelli C, Thompson JR, Abrams KR, et al. How should we use information about HWE in the meta-analyses of genetic association studies?. Int J Epidemiol. 02. 2008;37(1):136-46. [pmid: 18037675].
39 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. 05. 2010;63(5):513-23. [pmid: 19595577].
40 Prashker MJ, Meenan RF. The total costs of drug therapy for rheumatoid arthritis. A model based on costs of drug, monitoring, and toxicity. Arthritis Rheum. 03. 1995;38(3):318-25. [pmid: 7880185].
41 The Netherlands Organisation for Health Research and Development (ZonMw). Pharmacogenetic testing in the clinical setting: is screening for TPMT genotype a cost-effective treatment strategy? The first prospective randomized controlled trial within the Dutch health care system (project) (Project record). The Netherlands Organisation for Health Research and Development (ZonMw). 2006.
42 Sheffield LJ, Irving P, Gupta A, et al. Thiopurine methyltransferase and thiopurine metabolite testing in patients with inflammatory bowel disease who are taking thiopurine drugs. Pharmacogenomics. 07. 2009;10(7):1091-9. [pmid: 19604082].
43 Barlow N. Is TPMT testing cost-effective? A study of the use of a national service for TPMT in relation to the health economic debate on pharmacogenomic testing. Pathology News. 2009;(May):1-4.
44 Barlow N, Ford L, Berg J. Is TPMT testing cost-effective? A study of the use of a national service for TPMT in relation to the health economic debate on pharmacogenomic testing. Ann Clin Biochem. 2009;46(Suppl 1):91.
45 Colletti RB, Baldassano RN, Milov DE, et al. Variation in care in pediatric crohn disease. J Pediatr Gastroenterol Nutr. 09. 2009;49(3):297-303. [pmid: 19590456].
46 Ansari A, Arenas M, Greenfield SM, et al. Prospective evaluation of the pharmacogenetics of azathioprine in the treatment of inflammatory bowel disease. Aliment Pharmacol Ther. 10. 15. 2008;28(8):973-83. [pmid: 18616518].
47 Palmieri O, Latiano A, Bossa F, et al. Sequential evaluation of thiopurine methyltransferase, inosine triphosphate pyrophosphatase, and HPRT1 genes polymorphisms to explain thiopurines' toxicity and efficacy.[erratum appears in Aliment Pharmacol Ther. 2007 Sep 15;26(6):968]. Aliment Pharmacol Ther. 09. 1. 2007;26(5):737-45. [pmid: 17697207].
48 Stocco G, Martelossi S, Barabino A, et al. Glutathione-S-transferase genotypes and the adverse effects of azathioprine in young patients with inflammatory bowel disease. Inflamm Bowel Dis. 01. 2007;13(1):57-64. [pmid: 17206640].
49 Lindqvist M, Hindorf U, Almer S, et al. No induction of thiopurine methyltransferase during thiopurine treatment in inflammatory bowel disease. Nucleosides Nucleotides Nucleic Acids. 2006;25(9–11):1033-7. [pmid: 17065060].
50 Hindorf U, Lindqvist M, Hildebrand H, et al. Adverse events leading to modification of therapy in a large cohort of patients with inflammatory bowel disease. Aliment Pharmacol Ther. 07. 15. 2006;24(2):331-42. [pmid: 16842460].
51 Stocco G, Martelossi S, Barabino A, et al. TPMT genotype and the use of thiopurines in paediatric inflammatory bowel disease. Dig Liver Dis. 12. 2005;37(12):940-5. [pmid: 16202677].
52 von Ahsen N, Armstrong VW, Behrens C, et al. Association of inosine triphosphatase 94C>A and thiopurine S-methyltransferase deficiency with adverse events and study drop-outs under azathioprine therapy in a prospective Crohn disease study.[erratum appears in Clin Chem. 2006 Aug;52(8):1628 Note: Schutz, Ekkehard [added]]. Clin Chem. 12. 2005;51(12):2282-8. [pmid: 16214825].
53 Okada Y, Nakamura K, Kodama T, et al. Thiopurine methyltransferase genotype and phenotype status in Japanese patients with systemic lupus erythematosus. Biol Pharm Bull. 11. 2005;28(11):2117-9. [pmid: 16272700].
54 Derijks LJ, Gilissen LP, Engels LG, et al. Pharmacokinetics of 6-mercaptopurine in patients with inflammatory bowel disease: implications for therapy. Ther Drug Monit. 06. 2004;26(3):311-8. [pmid: 15167634].
55 Cuffari C, Dassopoulos T, Turnbough L, et al. Thiopurine methyltransferase activity influences clinical response to azathioprine in inflammatory bowel disease. Clin Gastroenterol Hepatol. 05. 2004;2(5):410-7. [pmid: 15118980].
56 Marinaki AM, Arenas M, Khan ZH, et al. Genetic determinants of the thiopurine methyltransferase intermediate activity phenotype in British Asians and Caucasians. Pharmacogenetics. 02. 2003;13(2):97-105. [pmid: 12563179].
57 Corominas H, Domenech M, Laiz A, et al. Is thiopurine methyltransferase genetic polymorphism a major factor for withdrawal of azathioprine in rheumatoid arthritis patients?. Rheumatology. 01. 2003;42(1):40-5. [pmid: 12509611].
58 Campbell S, Kingstone K, Ghosh S. Relevance of thiopurine methyltransferase activity in inflammatory bowel disease patients maintained on low-dose azathioprine. Aliment Pharmacol Ther. 03. 2002;16(3):389-98. [pmid: 11876691].
59 Stocco G, Martelossi S, Decorti G, et al. Pharmacogenetics of thiopurines: Can posology be guided by laboratory data. Radiol Oncol. 2004;38(2):101-9. +157.
60 Colletti RB, Baldassano RN, Milov DE, et al. Variation in initial 6-mercaptopurine dosage in pediatric Crohn's disease. Gastroenterol. 2006;130.
61 van Dieren J, van Vuuren H, Kuipers E, et al. Heterozygous polymorphisms in the genes encoding ITPA and TPMT*3A are not predictive for the development of adverse effects of azathioprine treatment in IBD patients. Gastroenterol. 2005;128.
62 Ansari AR, Soon SY, Lindsay J, et al. Thiopurine methyl transferase activity predicts both toxicity and clinical response to azathioprine in inflammatory bowel disease: The London IBD forum prospective study. Gastroenterol. 2004;126.
63 Zelinkova Z, Derrijks L, Stokkers P, et al. Inosine triphosphate pyrophosphatase gene mutation predicts myelosuppression in IBD patients treated with azathioprine. Gastroenterol. 2004;126.
64 Hurlburt K, Mayo M, Yeo A, et al. TPMT activity related to azathioprine dosing and treatment of autoimmune hepatitis. Hepatology. 2005;42(4, Suppl 1):291A.
65 Pageaux G, Masbou J, Brunschwig C, et al. Are hepatic toxic effects of thiopurine derivatives drugs related to thiopurine methyltransferase activity deficiency. Gastroenterol. 1997;112.
66 Wang L, Sullivan W, Toft D, et al. Thiopurine S-methyltransferase (TPMT) pharmacogenetics: Role of chaperone proteins in variant allozyme degradation. Clin Pharmacol Ther. 2003;73(2).
67 Watanabe K, Simmons J, Orchard T, et al. Allelic variants of thiopurine methyl transferase are associated with azathioprine induced leukopaenia. Gut. 2000;46(11).
68 Comer M, James I, D'Cruz D, et al. Erythrocyte thiopurine methyltransferase (TPMT) activity in rheumatoid arthritis patients experiencing azathioprine haematological toxicity. Br J Rheumatol. 1998;37.
69 Palmieri O, Latiano A, Bossa F, et al. Multiple genetic testing to explain intolerance to azathioprine. Gastroenterol. 2006;130.
70 Winter JW, Gaffney D, Shapiro D, et al. Assessment of thiopurine methyltransferase enzyme activity is superior to genotype in predicting myelosuppression following azathioprine therapy in patients with inflammatory bowel disease.[see comment]. Aliment Pharmacol Ther. 05. 1. 2007;25(9):1069-77. [pmid: 17439508].
71 Winter J, Gaffney D, Shapiro D, et al. Azathioprine tolerance in inflammatory bowel disease: Assess TPMT status by phenotype or genotype. Gut. 2007;56.
72 Gisbert JP, Nino P, Rodrigo L, et al. Thiopurine methyltransferase (TPMT) activity and adverse effects of azathioprine in inflammatory bowel disease: long-term follow-up study of 394 patients. Am J Gastroenterol. 12. 2006;101(12):2769-76. [pmid: 17026564].
73 Gisbert JP, Nino P, Rodrigo L, et al. Thiopurine methyltransferase (TPMT) activity and adverse effects of azathioprine in inflammatory bowel disease: Long-term follow-up study of 394 patients. Gastroenterol. 2007;132.
74 Hindorf U, Lindqvist M, Peterson C, et al. Pharmacogenetics during standardised initiation of thiopurine treatment in inflammatory bowel disease. Gut. 10. 2006;55(10):1423-31. [pmid: 16543290].
75 Hindorf U, Lindqvist M, Strom M, et al. Lack of association between the inosine triphosphate pyrophosphatase (ITPA) 94C > A polymorphism, the TPMT genotype, the baseline tpmt activity and adverse effects from thiopurine medication in inflammatory bowel disease. Gastroenterol. 2005;128.
76 Heneghan MA, Allan ML, Bornstein JD, et al. Utility of thiopurine methyltransferase genotyping and phenotyping, and measurement of azathioprine metabolites in the management of patients with autoimmune hepatitis. J Hepatol. 10. 2006;45(4):584-91. [pmid: 16876902].
77 Heneghan MA, Allan ML, Bornstein JD, et al. Utility of thiopurine methyltransferase genotyping and phenotyping and measurement of 6-thioguanine metabolites in the management of autoimmune hepatitis. Hepatology. 2003;38(4 Suppl 1):489A.
78 Hindorf U, Lindqvist M, Hildebrand H, et al. Adverse events leading to modification of therapy in a large cohort of azathioprine-treated patients with inflammatory bowel disease. Gastroenterol. 2006;130.
79 Czaja AJ, Carpenter HA. Thiopurine methyltransferase deficiency and azathioprine intolerance in autoimmune hepatitis. Dig Dis Sci. 05. 2006;51(5):968-75. [pmid: 16773433].
80 Czaja AJ, Carpenter HA. Thiopurine methyltransferase deficiency and azathioprine intolerance in autoimmune hepatitis. Hepatology. 2004;40(4, Suppl 1):418A.
81 Gearry RB, Roberts RL, Barclay ML, et al. Lack of association between the ITPA 94C>A polymorphism and adverse effects from azathioprine. Pharmacogenetics. 11. 2004;14(11):779-81. [pmid: 15564886].
82 Gearry RB, Barclay ML, Burt MJ, et al. Thiopurine S-methyltransferase (TPMT) genotype does not predict adverse drug reactions to thiopurine drugs in patients with inflammatory bowel disease. Aliment Pharmacol Ther. 08. 15. 2003;18(4):395-400. [pmid: 12940924].
83 Winter J, Walker A, Shapiro D, et al. Cost-effectiveness of thiopurine methyltransferase genotype screening in patients about to commence azathioprine therapy for treatment of inflammatory bowel disease.[see comment]. Aliment Pharmacol Ther. 09. 15. 2004;20(6):593-9. [pmid: 15352906].
84 Winter J, Walker A, Shapiro D, et al. TPMT genotype: Is this a cost effective assay for patients about to begin azathioprine treatment for inflammatory bowel disease. Gut. 2004;53.
85 Derijks L, Gilissen L, Engels L, et al. 6-Mercaptopurine metabolites in patients with inflammatory bowel disease. Proceedings of the Sixth Congress of the European Association for Clinical Pharmacology and Therapeutics. European collaboration: Towards drug development and rational drug therapy. 2003:70.
86 Marinaki AM, Ansari A, Duley JA, et al. Adverse drug reactions to azathioprine therapy are associated with polymorphism in the gene encoding inosine triphosphate pyrophosphatase (ITPase). Pharmacogenetics. 03. 2004;14(3):181-7. [pmid: 15167706].
87 Ansari AR, Marinaki T, Arenas M, et al. Mutation in the Itpa Gene Predicts Intolerance to Azathioprine. Dig Dis Week Abstr Itinerary Planner. 2003;2003.
88 Campbell S, Kingstone K, Ghosh S. Relevance of thiopurine methyltransferase activity in inflammatory bowel disease patients maintained on low dose azathioprine. Gut. 2002;50.
89 Black AJ, McLeod HL, Capell HA, et al. Thiopurine methyltransferase genotype predicts therapy-limiting severe toxicity from azathioprine. Ann Intern Med. 11. 1. 1998;129(9):716-8. [pmid: 9841604].
90 Black A, Capell H, McLeod H, et al. Do genetic polymorphism's influence the occurrence of azathioprine (AZA) toxicity in Rheumatic diseases. Br J Rheumatol. 1998;37.
91 Stolk JN, Boerbooms AM, De Abreu RA, et al. Reduced thiopurine methyltransferase activity and development of side effects of azathioprine treatment in patients with rheumatoid arthritis. Arthritis Rheum. 10. 1998;41(10):1858-66. [pmid: 9778228].
92 Stolk J, Boerbooms A, De Abreu R, et al. Are severe non-hematologic side-effects on azathioprine treatment caused by altered purine enzyme activities. Arthritis Rheum. 1996;39.
93 Snow JL, Gibson LE. The role of genetic variation in thiopurine methyltransferase activity and the efficacy and/or side effects of azathioprine therapy in dermatologic patients.[see comment]. Arch Dermatol. 02. 1995;131(2):193-7. [pmid: 7857117].
94 Snow JL, Gibson LE. The role of genetic variation in thiopurine methyltransferase activity and the efficacy and/or side effects of azathioprine therapy in dermatologic patients. Journal of Investigative Dermatology. 1994;102(4).
95 Kerstens PJ, Stolk JN, De Abreu RA, et al. Azathioprine-related bone marrow toxicity and low activities of purine enzymes in patients with rheumatoid arthritis. Arthritis Rheum. 01. 1995;38(1):142-5. [pmid: 7818564].
96 Kerstens P, Lambooy L, Boerbooms A, et al. Low levels of purine enzymes as a cause of azathioprine induced bone marrow toxicity in RA. Arthritis Rheum. 1992;35.
97 Walsh M, Royston C, Srinivas M, et al. Monitoring azathioprine (AZA) treatment in inflammatory bowel disease (IED): Rituals REvisited but not revised!. Gastroenterol. 2008;134(4, Suppl 1).
98 Walsh M, Royston C, Srinivas M, et al. Monitoring azathioprine treatment in inflammatory bowel disease: Rituals re-visited - But not revised!. Gut. 2008;57(Suppl 1):A37-A38.
99 Schmeling H, Abdelhaleem M, Benseler S, et al. Role of TPMT genotyping and azathioprine metabolites in predicting toxicity of azathioprine in PSLE patients. Arthritis Rheum. 2007;56(12):4265-6.
100 Schmeling H, Abdelhaleem M, Benseler S, et al. Role of TPMT genotyping and azathioprine metabolites in predicting toxicity of azathioprine in pediatric SLE patients. Zeitschrift fuer Rheumatologie. 2007;66(7):641.
101 Ansari AR, Soon S, Raoof S, et al. Pharmacogenetic profiling in azathioprine therapy: The role of TPMT, ITPA and MTHFR polymorphisms in drug toxicity. Gastroenterol. 2004;126.
102 Xin H, Fischer C, Schwab M, et al. Effects of aminosalicylates on thiopurine S-methyltransferase activity: an ex vivo study in patients with inflammatory bowel disease. Aliment Pharmacol Ther. 05. 1. 2005;21(9):1105-9. [pmid: 15854172].
103 Xin HW, Fischer C, Schwab M, et al. Thiopurine S-methyltransferase as a target for drug interactions. Eur J Clin Pharmacol. 07. 2005;61(5–6):395-8. [pmid: 15952020].
104 Gisbert JP, Gomollon F, Cara C, et al. Thiopurine methyltransferase activity in Spain: a study of 14,545 patients. Dig Dis Sci. 05. 2007;52(5):1262-9. [pmid: 17334911].
105 Dilger K, Schaeffeler E, Lukas M, et al. Monitoring of thiopurine methyltransferase activity in postsurgical patients with Crohn's disease during 1 year of treatment with azathioprine or mesalazine. Ther Drug Monit. 02. 2007;29(1):1-5. [pmid: 17304143].
106 Zhang LR, Song DK, Zhang W, et al. Efficient screening method of the thiopurine methyltransferase polymorphisms for patients considering taking thiopurine drugs in a Chinese Han population in Henan Province (central China). Clinica Chimica Acta. 02. 2007;376(1–2):45-51.
107 Oselin K, Anier K, Tamm R, et al. Determination of thiopurine S-methyltransferase (TPMT) activity by comparing various normalization factors: reference values for Estonian population using HPLC-UV assay. Journal of Chromatography B: Analytical Technologies in the Biomedical & Life Sciences. 04. 13. 2006;834(1–2):77-83.
108 Khalil MN, Erb N, Khalil PN, et al. Interference free and simplyfied liquid chromatography-based determination of thiopurine S-methyltransferase activity in erythrocytes.[erratum appears in J Chromatogr B Analyt Technol Biomed Life Sci. 2005 Sep 25;824(1–2):348–50]. Journal of Chromatography B: Analytical Technologies in the Biomedical & Life Sciences. 07. 5. 2005;821(1):105-11.
109 Heckmann JM, Lambson EM, Little F, et al. Thiopurine methyltransferase (TPMT) heterozygosity and enzyme activity as predictive tests for the development of azathioprine-related adverse events. J Neuro Sci. 04. 15. 2005;231(1–2):71-80.
110 Brouwer C, De Abreu RA, Keizer-Garritsen JJ, et al. Thiopurine methyltransferase in acute lymphoblastic leukaemia: biochemical and molecular biological aspects. Eur J Cancer. 03. 2005;41(4):613-23. [pmid: 15737567].
111 Hindorf U, Peterson C, Almer S. Assessment of thiopurine methyltransferase and metabolite formation during thiopurine therapy: results from a large Swedish patient population. Ther Drug Monit. 12. 2004;26(6):673-8. [pmid: 15570193].
112 Ford LT, Cooper SC, Lewis MJ, et al. Reference intervals for thiopurine S-methyltransferase activity in red blood cells using 6-thioguanine as substrate and rapid non-extraction liquid chromatography.[see comment]. Ann Clin Biochem. 07. 2004;41(Pt 4):303-8. [pmid: 15298742].
113 Ganiere-Monteil C, Medard Y, Lejus C, et al. Phenotype and genotype for thiopurine methyltransferase activity in the French Caucasian population: impact of age. Eur J Clin Pharmacol. 04. 2004;60(2):89-96. [pmid: 15022030].
114 Shipkova M, Niedmann PD, Armstrong VW, et al. Determination of thiopurine methyltransferase activity in isolated human erythrocytes does not reflect putative in vivo enzyme inhibition by sulfasalazine. Clin Chem. 02. 2004;50(2):438-41. [pmid: 14752016].
115 Indjova D, Shipkova M, Atanasova S, et al. Determination of thiopurine methyltransferase phenotype in isolated human erythrocytes using a new simple nonradioactive HPLC method. Ther Drug Monit. 10. 2003;25(5):637-44. [pmid: 14508388].
116 Keizer-Garritsen JJ, Brouwer C, Lambooy LH, et al. Measurement of thiopurine S-methyltransferase activity in human blood samples based on high-performance liquid chromatography: reference values in erythrocytes from children. Ann Clin Biochem. 01. 2003;40(Pt 1):86-93. [pmid: 12542916].
117 Menor C, Fueyo J, Escribano O, et al. Thiopurine methyltransferase activity in a Spanish population sample: decrease of enzymatic activity in multiple sclerosis patients. Mult Scler. 05. 2002;8(3):243-8. [pmid: 12120697].
118 Anglicheau D, Sanquer S, Loriot MA, et al. Thiopurine methyltransferase activity: new conditions for reversed-phase high-performance liquid chromatographic assay without extraction and genotypic-phenotypic correlation. Journal of Chromatography B: Analytical Technologies in the Biomedical & Life Sciences. 06. 25. 2002;773(2):119-27.
119 Dubinsky MC, Yang H, Hassard PV, et al. 6-MP metabolite profiles provide a biochemical explanation for 6-MP resistance in patients with inflammatory bowel disease.[see comment]. Gastroenterol. 04. 2002;122(4):904-15.
120 Dewit O, Vanheuverzwyn R, Desager JP, et al. Interaction between azathioprine and aminosalicylates: an in vivo study in patients with Crohn's disease. Aliment Pharmacol Ther. 01. 2002;16(1):79-85. [pmid: 11856081].
121 Lennard L, Chew TS, Lilleyman JS. Human thiopurine methyltransferase activity varies with red blood cell age. British Journal of Clinical Pharmacology. 11. 2001;52(5):539-46. [pmid: 11736862].
122 Alves S, Amorim A, Ferreira F, et al. Influence of the variable number of tandem repeats located in the promoter region of the thiopurine methyltransferase gene on enzymatic activity. Clin Pharmacol Ther. 08. 2001;70(2):165-74. [pmid: 11503011].
123 Coulthard SA, Howell C, Robson J, et al. The relationship between thiopurine methyltransferase activity and genotype in blasts from patients with acute leukemia. Blood. 10. 15. 1998;92(8):2856-62. [pmid: 9763570].
124 Kroplin T, Weyer N, Gutsche S, et al. Thiopurine S-methyltransferase activity in human erythrocytes: a new HPLC method using 6-thioguanine as substrate. Eur J Clin Pharmacol. 05. 1998;54(3):265-71. [pmid: 9681671].
125 Micheli V, Jacomelli G, Fioravanti A, et al. Thiopurine methyltransferase activity in the erythrocytes of adults and children: and HPLC-linked assay. Clinica Chimica Acta. 03. 18. 1997;259(1–2):161-8.
126 Klemetsdal B, Straume B, Lysaa R, et al. Erythrocyte fraction affects red blood cell thiopurine methyltransferase activity. Eur J Clin Pharmacol. 1995;48(6):495-9. [pmid: 8582469].
127 Lennard L, Singleton HJ. High-performance liquid chromatographic assay of human red blood cell thiopurine methyltransferase activity. Journal of Chromatography B: Biomedical Applications. 11. 4. 1994;661(1):25-33.
128 Jacqz-Aigrain E, Bessa E, Medard Y, et al. Thiopurine methyltransferase activity in a French population: h.p.l.c. assay conditions and effects of drugs and inhibitors. British Journal of Clinical Pharmacology. 07. 1994;38(1):1-8. [pmid: 7946931].
129 Chocair PR, Duley JA, Sabbaga E, et al. Fast and slow methylators: do racial differences influence risk of allograft rejection?. Q J Med. 06. 1993;86(6):359-63. [pmid: 8171183].
130 Szumlanski CL, Honchel R, Scott MC, et al. Human liver thiopurine methyltransferase pharmacogenetics: biochemical properties, liver-erythrocyte correlation and presence of isozymes. Pharmacogenetics. 08. 1992;2(4):148-59. [pmid: 1306116].
131 Tinel M, Berson A, Pessayre D, et al. Pharmacogenetics of human erythrocyte thiopurine methyltransferase activity in a French population. British Journal of Clinical Pharmacology. 12. 1991;32(6):729-34. [pmid: 1768566].
132 Woodson LC, Ames MM, Selassie CD, et al. Thiopurine methyltransferase. Aromatic thiol substrates and inhibition by benzoic acid derivatives. Molecular Pharmacology. 11. 1983;24(3):471-8. [pmid: 6633508].
133 Woodson LC, Dunnette JH, Weinshilboum RM. Pharmacogenetics of human thiopurine methyltransferase: kidney-erythrocyte correlation and immunotitration studies. Journal of Pharmacology & Experimental Therapeutics. 07. 1982;222(1):174-81. [pmid: 7086699].
134 Weinshilboum RM, Raymond FA, Pazmino PA. Human erythrocyte thiopurine methyltransferase: radiochemical microassay and biochemical properties. Clinica Chimica Acta. 05. 2. 1978;85(3):323-33.
135 Zhang B, Xu X, Zeng X, et al. Correlation of thiopurine methyltransferase activity and 6-thioguanine nucleotide concentration in Han Chinese patients treated with azathioprine 25 to 100 mg: A 1-year, single-center, prospective study. Curr Therap Res - Clin Experiment. 2006;67(4):270-82.
136 Lentz JJ, Cunnigham J, Winland M, et al. Performance evaluation of a thiopurine methyltransferase (TPMT) enzyme activity assay by reversed-phase HPLC. Am J Gastroenterol. 2000;95(9).
137 Wong JL, Galloway T, Biggs L, et al. Assay of thiopurine methyltransferase (TPMT) for thiopurine therapy: The effect of storage on red blood cell TPMT activity. Gastroenterol. 2002;122(4 Suppl 1):A-222.
138 Hindorf U, Johansson M, Eriksson A, et al. Mercaptopurine treatment should be considered in azathioprine intolerant patients with inflammatory bowel disease. Aliment Pharmacol Ther. 03. 15. 2009;29(6):654-61. [pmid: 19183142].
139 Schaeffeler E, Zanger UM, Eichelbaum M, et al. Highly multiplexed genotyping of thiopurine s-methyltransferase variants using MALD-TOF mass spectrometry: reliable genotyping in different ethnic groups.[see comment]. Clin Chem. 10. 2008;54(10):1637-47. [pmid: 18687736].
140 Haglund S, Taipalensuu J, Peterson C, et al. IMPDH activity in thiopurine-treated patients with inflammatory bowel disease - relation to TPMT activity and metabolite concentrations. British Journal of Clinical Pharmacology. 01. 2008;65(1):69-77. [pmid: 17662091].
141 Chowdhury J, Kagiala GV, Pushpakom S, et al. Microfluidic platform for single nucleotide polymorphism genotyping of the thiopurine S-methyltransferase gene to evaluate risk for adverse drug events. J Mol Diagn. 09. 2007;9(4):521-9. [pmid: 17690215].
142 Ford L, Graham V, Berg J. Whole-blood thiopurine S-methyltransferase activity with genotype concordance: a new, simplified phenotyping assay. Ann Clin Biochem. 09. 2006;43(Pt 5):354-60. [pmid: 17036413].
143 Indjova D, Atanasova S, Shipkova M, et al. Phenotypic and genotypic analysis of thiopurine s-methyltransferase polymorphism in the bulgarian population. Ther Drug Monit. 10. 2003;25(5):631-6. [pmid: 14508387].
144 Dauer M, Schulze J, Loher F, et al. Determination of thiopurine S-methyltransferase phenotype using thin-layer chromatography and quantitative scanning. Eur J Clin Pharmacol. 04. 2002;58(1):41-4. [pmid: 11956672].
145 Dervieux T, Medard Y, Verpillat P, et al. Possible implication of thiopurine S-methyltransferase in occurrence of infectious episodes during maintenance therapy for childhood lymphoblastic leukemia with mercaptopurine. Leukemia. 11. 2001;15(11):1706-12. [pmid: 11681411].
146 Menor C, Fueyo JA, Escribano O, et al. Determination of thiopurine methyltransferase activity in human erythrocytes by high-performance liquid chromatography: comparison with the radiochemical method. Ther Drug Monit. 10. 2001;23(5):536-41. [pmid: 11591900].
147 Decaux G, Horsmans Y, Houssiau F, et al. High 6-thioguanine nucleotide levels and low thiopurine methyltransferase activity in patients with lupus erythematosus treated with azathioprine. Am J Therapeut. 05. 2001;8(3):147-50.
148 Coulthard SA, Rabello C, Robson J, et al. A comparison of molecular and enzyme-based assays for the detection of thiopurine methyltransferase mutations. Br J Haematol. 09. 2000;110(3):599-604. [pmid: 10997970].
149 Alves S, Prata MJ, Ferreira F, et al. Screening of thiopurine S-methyltransferase mutations by horizontal conformation-sensitive gel electrophoresis. Hum Mutat. 2000;15(3):246-53. [pmid: 10679940].
150 Ganiere-Monteil C, Pineau A, Kergueris MF, et al. Thiopurine methyl transferase activity: new extraction conditions for high-performance liquid chromatographic assay. Journal of Chromatography B: Biomedical Sciences & Applications. 04. 30. 1999;727(1–2):235-9.
151 Dervieux T, Medard Y, Baudouin V, et al. Thiopurine methyltransferase activity and its relationship to the occurrence of rejection episodes in paediatric renal transplant recipients treated with azathioprine. British Journal of Clinical Pharmacology. 12. 1999;48(6):793-800. [pmid: 10594482].
152 Escousse A, Guedon F, Mounie J, et al. 6-Mercaptopurine pharmacokinetics after use of azathioprine in renal transplant recipients with intermediate or high thiopurine methyl transferase activity phenotype. J Pharm Pharmacol. 11. 1998;50(11):1261-6. [pmid: 9877312].
153 Medard Y, Nafa S, Jacqz-Aigrain E. Thiopurine methyltransferase activity: new high-performance liquid chromatographic assay conditions. Journal of Chromatography. 1997. 10. 24. B, Biomedical Sciences & Applications. 700(1–2):275-7.
154 Lee EJ, Kalow W. Thiopurine S-methyltransferase activity in a Chinese population. Clin Pharmacol Ther. 07. 1993;54(1):28-33. [pmid: 8330462].
155 Johnson-Davis K, Juenke J, Pickering J, et al. An enzymatic assay used to identify patients with low thiopurine methyltransferase (TPMT) activity. Clin Chem. 2008;54.
156 Lindqvist M, Almer S, Hildebrand H, et al. Real time PCR methodology for quantification of thiopurine methyltransferase (TPMT) gene expression. Proceedings of the American Association for Cancer Research Annual Meeting. 2002;43:428-9.
157 Stassen PM, Derks RP, Kallenberg CG, et al. Thiopurinemethyltransferase (TPMT) genotype and TPMT activity in patients with anti-neutrophil cytoplasmic antibody-associated vasculitis: relation to azathioprine maintenance treatment and adverse effects. Ann Rheum Dis. 05. 2009;68(5):758-9. [pmid: 19366895].
158 Gardiner SJ, Gearry RB, Begg EJ, et al. Thiopurine dose in intermediate and normal metabolizers of thiopurine methyltransferase may differ three-fold. Clin Gastroenterol Hepatol. 06. 2008;6(6):654-60. [pmid: 18467186].
159 Hindorf U, Lyrenas E, Nilsson A, et al. Monitoring of long-term thiopurine therapy among adults with inflammatory bowel disease. Scand J Gastroenterol Suppl. 11. 2004;39(11):1105-12.
160 Haglund S, Lindqvist M, Almer S, et al. Pyrosequencing of TPMT alleles in a general Swedish population and in patients with inflammatory bowel disease.[erratum appears in Clin Chem. 2004 Apr;50(4):788]. Clin Chem. 02. 2004;50(2):288-95. [pmid: 14656901].
161 Ansari A, Hassan C, Duley J, et al. Thiopurine methyltransferase activity and the use of azathioprine in inflammatory bowel disease. Aliment Pharmacol Ther. 10. 2002;16(10):1743-50. [pmid: 12269967].
162 Langley PG, Underhill J, Tredger JM, et al. Thiopurine methyltransferase phenotype and genotype in relation to azathioprine therapy in autoimmune hepatitis. J Hepatol. 10. 2002;37(4):441-7. [pmid: 12217596].
163 Schwab M, Schaffeler E, Marx C, et al. Azathioprine therapy and adverse drug reactions in patients with inflammatory bowel disease: impact of thiopurine S-methyltransferase polymorphism.[see comment]. Pharmacogenetics. 08. 2002;12(6):429-36. [pmid: 12172211].
164 Daperno M, Canaparo R, Sostegni R, et al. Genotype and phenotype analysis of thiopurine-methyl-transferase (TPMT) in a northern Italian. Gastroenterol. 2008;134.
165 Allan M, Tendler D, Muir A, et al. Utility of thiopurine methyltransferase pharmacogenetic testing and monitoring of azathioprine metabolites in the management of autoimmune hepatitis. Gastroenterol. 2002;122.
166 Taylor E, Matsutani M, Barry M, et al. TPMT (thiopurine methyltransferase) genotype-phenotype accuracy in IBD patients. Gastroenterol. 2002;122(4 Suppl 1):A-222.
167 Hindorf U, Jahed K, Bergquist A, et al. Characterisation and utility of thiopurine methyltransferase and thiopurine metabolite measurements in autoimmune hepatitis. J Hepatol. 2010;52(1):106-11. [pmid: 19906459].
168 Vestergaard T, Bygum A. An audit of thiopurine methyltransferase genotyping and phenotyping before intended azathioprine treatment for dermatological conditions. Clin Experiment Dermatol. 2010;35(2):140-4.
169 Banerjee S, Bishop WP. Evolution of thiopurine use in pediatric inflammatory bowel disease in an academic center.[see comment]. J Pediatr Gastroenterol Nutr. 09. 2006;43(3):324-30. [pmid: 16954954].
170 Bezier M, Reguiai Z, Vitry F, et al. Thiopurine S-methyltransferase genotypic analysis in autoimmune bullous diseases. European Journal of Dermatology. 09. 2008;18(5):512-7. [pmid: 18693152].
171 Tamori A, Shinzaki M, Kosaka S, et al. Thiopurine S-methyltransferase gene polymorphism in Japanese patients with autoimmune liver diseases. Liver Internat. 02. 2007;27(1):95-100.
172 De RL, Van Dieren JM, Van Deventer HJ, et al. Pharmacogenetics of thiopurine therapy in paediatric IBD patients. Aliment Pharmacol Ther. 04. 15. 2006;23(8):1137-41. [pmid: 16611274].
173 Zelinkova Z, Derijks LJ, Stokkers PC, et al. Inosine triphosphate pyrophosphatase and thiopurine s-methyltransferase genotypes relationship to azathioprine-induced myelosuppression. Clin Gastroenterol Hepatol. 01. 2006;4(1):44-9. [pmid: 16431304].
174 Jun JB, Cho DY, Kang C, et al. Thiopurine S-methyltransferase polymorphisms and the relationship between the mutant alleles and the adverse effects in systemic lupus erythematosus patients taking azathioprine. Clinical & Experimental Rheumatology. 11. 2005;23(6):873-6. [pmid: 16396707].
175 Reuther LO, Sonne J, Larsen NE, et al. Pharmacological monitoring of azathioprine therapy. Scand J Gastroenterol Suppl. 09. 2003;38(9):972-7.
176 Hibi T, Naganuma M, Kitahora T, et al. Low-dose azathioprine is effective and safe for maintenance of remission in patients with ulcerative colitis.[see comment]. J Gastroenterol. 2003;38(8):740-6. [pmid: 14505127].
177 Dubinsky MC, Lamothe S, Yang HY, et al. Pharmacogenomics and metabolite measurement for 6-mercaptopurine therapy in inflammatory bowel disease. Gastroenterol. 04. 2000;118(4):705-13.
178 Naughton MA, Battaglia E, O'Brien S, et al. Identification of thiopurine methyltransferase (TPMT) polymorphisms cannot predict myelosuppression in systemic lupus erythematosus patients taking azathioprine. Rheumatology. 07. 1999;38(7):640-4. [pmid: 10461478].
179 Ishioka S, Hiyama K, Sato H, et al. Thiopurine methyltransferase genotype and the toxicity of azathioprine in Japanese.[see comment]. Internal Med. 12. 1999;38(12):944-7. [pmid: 10628931].
180 Jojic N, Urosevic J, Bojic B, et al. Determination of thiopurine methyltransferase genotype in the patients with inflammatory bowel disease before and during azathioprine therapy. Arch Gastroenterohepatol. 2003;22(1–2):5-9.
181 Kim JH, Cheon JH, Hong SS, et al. Can we predict highly frequent myelotoxicity during azathioprine/6-mercaptopurine treatment in Korean patients with inflammatory bowel disease by thiopurine methyltransferase genotyping and phenotyping or inosine triphosphate pyrophosphatase genotyping? A multicenter study. Gastroenterol. 2008;134.
182 Lopez AJ, Schwab M, Witt H, et al. The impact of genetic variants in TPMT, ITPA, MTHFR, SPINK1 and PRSS1 on azathioprine-induced pancreatitis. Gastroenterol. 2006;130.
183 Katsanos K, Ferrante M, Joossens M, et al. The MDR1 G2677T polymorphism is associated with gastrointestinal intolerance to azathioprine. Gastroenterol. 2006;130(4, Suppl 2):A199-A200.
184 Curvers W, Derijks L, Stokkers P, et al. No Predictive Value of Tpmt Genotyping for Leukopenia Or Hepatotoxicity During Azathioprine Therapy in Inflammatory Bowel Disease. Dig Dis Week Abstr Itinerary Planner. 2003;2003.
185 Curvers W, Gilissen L, Derijks L, et al. Pharmacokinetic Analysis of 6-Mercaptopurine in Patients with Inflammatory Bowel Disease. Dig Dis Week Abstr Itinerary Planner. 2003;2003.
186 Seddik M, Texier F, Ferrari N, et al. Thiopurine S-Methyltransferase Genotyping Does Not Predict Azathioprine-Induced Myelosuppression in Crohn'S Disease. Dig Dis Week Abstr Itinerary Planner. 2003;2003.
187 Qasim A, Molley C, McLoughlin R, et al. Absolute Leukocyte Count and Its Correlation with Thiopurine Methyl Transferase (Tpmt) Activity in Inflammatory Bowel Disease (Ibd) Patients Receiving Azathioprine (Aza)/6-Mercaptopurine (6Mp). Dig Dis Week Abstr Itinerary Planner. 2003;2003.
188 Rietdijk ST, Bartelsman J, Hommes DW, et al. Genetic polymorphisms of the thiopurine S-methyltransferase (TPMT) locus in patients treated with azathioprine for inflammatory bowel disease. Gastroenterol. 2001;120.
189 Shobowale-Bakre M, Hassan C, Ansari A, et al. Predicting drug toxicity and non-response: Azathioprine and thiopurine methyltransferase as a metabolic model. J Inherit Metabolic Dis. 2000;23.
190 Tani C, Mosca M, Colucci R, et al. Genetic polymorphisms of thiopurine S-methyltransferase in a cohort of patients with systemic autoimmune diseases. Clin Experiment Rheum. 2009;27(2):321-4.
191 Kolorz M, Bartosova L, Hosek J, et al. Importance of thiopurine S-methyltransferase gene polymorphisms for prediction of azathioprine toxicity. Neuroendocrinol Let. 2009;30(Suppl1):137-42. [pmid: 20027160].
192 Shah JA, Edwards CM, Probert CS. Should azathioprine and 5-aminosalicylates be coprescribed in inflammatory bowel disease?: an audit of adverse events and outcome. Eur J Gastroenterol Hepatol. 03. 2008;20(3):169-73. [pmid: 18301295].
193 Firooz A, Ghandi N, Hallaji Z, et al. Role of thiopurine methyltransferase activity in the safety and efficacy of azathioprine in the treatment of pemphigus vulgaris. Arch Dermatol. 09. 2008;144(9):1143-7. [pmid: 18794458].
194 Kwan LY, Devlin SM, Mirocha JM, et al. Thiopurine methyltransferase activity combined with 6-thioguanine metabolite levels predicts clinical response to thiopurines in patients with inflammatory bowel disease. Dig Liver Dis. 06. 2008;40(6):425-32. [pmid: 18304898].
195 Schedel J, Godde A, Schutz E, et al. Impact of thiopurine methyltransferase activity and 6-thioguanine nucleotide concentrations in patients with chronic inflammatory diseases. Ann N Y Acad Sci. 06. 2006;1069:477-91. [pmid: 16855176].
196 Kader HA, Wenner WJ Jr, Telega GW, et al. Normal thiopurine methyltransferase levels do not eliminate 6-mercaptopurine or azathioprine toxicity in children with inflammatory bowel disease. J Clin Gastroenterol. 06. 2000;30(4):409-13. [pmid: 10875470].
197 Lennard L, Van Loon JA, Weinshilboum RM. Pharmacogenetics of acute azathioprine toxicity: relationship to thiopurine methyltransferase genetic polymorphism. Clin Pharmacol Ther. 08. 1989;46(2):149-54. [pmid: 2758725].
198 Gubanich P, Achkar DP, Lashner B, et al. Thiopurine methyl transferase (TPMT) phenotype as a predictor of clinical response and side effect profile in a population of IBD patients. Am J Gastroenterol. 2004;99(10, Suppl S):S269-S270.
199 Domenech E, Garcia-Planella E, Fluvia L, et al. Clinical Implications of Thiopurine-Methyltransferase Activity (Tpmte) Induction by Azathioprine (Aza) Treatment in Patients with Inflammatory Bowel Disease (Ibd). Dig Dis Week Abstr Itinerary Planner. 2003;2003.
200 Wong JL, Lowes J, Biggs L, et al. The role of thiopurine methyltransferase (TPMT) activity assay before commencing thiopurine drugs in inflammatory bowel disease (IBD). Gastroenterol. 2002;122(4 Suppl 1):A-222.
201 Moloney M, Langley P, McFarlane I. Azathioprine tolerance is related to TPMT activity in autoimmune hepatitis (AIH). Gastroenterol. 1997;112.
202 Stolk J, Boerbooms A, De Abreu R, et al. The predictive value of thiopurine-methyltransferase activity for the development of toxicity of azathioprine in the treatment of rheumatoid arthritis. Br J Rheumatol. 1997;36.
203 Bastida G, Nos P, Aguas M, et al. Incidence, risk factors and clinical course of thiopurine-induced liver injury in patients with inflammatory bowel disease. Aliment Pharmacol Ther. 2005;22(9):775-82. [pmid: 16225485].
204 Compagni A, Bartoli S, Buehrlen B, et al. Avoiding adverse drug reactions by pharmacogenetic testing: a systematic review of the economic evidence in the case of TPMT and AZA-induced side effects. [Review] [32 refs]. Int J Technol Assess Health Care. 2008;24(3):294-302. [pmid: 18601797].
205 Priest VL, Begg EJ, Gardiner SJ, et al. Pharmacoeconomic analyses of azathioprine, methotrexate and prospective pharmacogenetic testing for the management of inflammatory bowel disease. Pharmacoeconomics. 2006;24(8):767-81. [pmid: 16898847].
206 Dubinsky MC, Reyes E, Ofman J, et al. A cost-effectiveness analysis of alternative disease management strategies in patients with Crohn's disease treated with azathioprine or 6-mercaptopurine. Am J Gastroenterol. 10. 2005;100(10):2239-47. [pmid: 16181376].
207 Sayani FA, Prosser C, Bailey RJ, et al. Thiopurine methyltransferase enzyme activity determination before treatment of inflammatory bowel disease with azathioprine: effect on cost and adverse events. Can J Gastroenterol. 03. 2005;19(3):147-51. [pmid: 15776134].
208 Oh KT, Anis AH, Bae SC. Pharmacoeconomic analysis of thiopurine methyltransferase polymorphism screening by polymerase chain reaction for treatment with azathioprine in Korea. Rheumatology. 02. 2004;43(2):156-63. [pmid: 12923290].
209 Marra CA, Esdaile JM, Anis AH. Practical pharmacogenetics: the cost effectiveness of screening for thiopurine s-methyltransferase polymorphisms in patients with rheumatological conditions treated with azathioprine. J Rheum. 12. 2002;29(12):2507-12. [pmid: 12465143].
210 Tavadia SM, Mydlarski PR, Reis MD, et al. Screening for azathioprine toxicity: a pharmacoeconomic analysis based on a target case. J Am Acad Dermatol. 04. 2000;42(4):628-32. [pmid: 10727309].
211 Gurwitz D, Rodriguez-Antona C, Payne K, et al. Improving pharmacovigilance in Europe: TPMT genotyping and phenotyping in the UK and Spain. Eur J Hum Genet. 08. 2009;17(8):991-8. [pmid: 19223932].
212 Hagaman JT, Kinder BW, Eckman MH. Thiopurine S-methyltranferase testing in idiopathic pulmonary fibrosis: A pharmacogenetic cost-effectiveness analysis. Lung. 2010;188(2):125-32. [pmid: 20066544].
213 Schaeffeler E, Eichelbaum M, Reinisch W, et al. Three novel thiopurine S-methyltransferase allelic variants (TPMT*20, *21, *22) - association with decreased enzyme function. Hum Mutat. 09. 2006;27(9):976. 2006. [pmid: 16917910].
214 Gearry RB, Barclay ML, Roberts RL, et al. Thiopurine methyltransferase and 6-thioguanine nucleotide measurement: early experience of use in clinical practice. Internal Med J. 10. 2005;35(10):580-5. [pmid: 16207256].
215 Tsui NB. Multiple thiopurine S-methyltransferase variation detection: a step toward personalized medicine.[comment]. Clin Chem. 10. 2008;54(10):1598-9. [pmid: 18824573].
216 Krynetski EY, Schuetz JD, Galpin AJ, et al. A single point mutation leading to loss of catalytic activity in human thiopurine S-methyltransferase. Proc Natl Acad Sci U.S.A. 02. 14. 1995;92(4):949-53. [pmid: 7862671].
217 Duffy MJ, Crown J. A personalized approach to cancer treatment: how biomarkers can help. [Review] [76 refs]. Clin Chem. 11. 2008;54(11):1770-9. [pmid: 18801934].
218 Donnelly JG. Pharmacogenetics in cancer chemotherapy: balancing toxicity and response. [Review] [50 refs]. Ther Drug Monit. 04. 2004;26(2):231-5. [pmid: 15228171].
219 Kurzawski M, Dziewanowski K, Lener A, et al. TPMT but not ITPA gene polymorphism influences the risk of azathioprine intolerance in renal transplant recipients. Eur J Clin Pharmacol. 05. 2009;65(5):533-40. [pmid: 19229528].
220 Plebani M. Errors in clinical laboratories or errors in laboratory medicine?. Clin Chem Lab Med. 2006;44(6):750-9. [pmid: 16729864].
221 U.S.Food and Drug Administration. Collection, Transport, Preparation, and Storage of Specimens for Molecular Methods; Approved Guideline. MM13-A. 2005;25(31).
222 Fraser CG. Biological variation: from principles to practice. Washington D.C. Amer Assn for Clinical Chemistry. 2001.
223 The Federal Registrar. U.S. Department of Health and Human Services: Clinical Laboratory Improvement Amendments of 1988; Final Rules and Notice. 42 CFR Part 493. 1992;57.
224 Chen B, Gagnon M, Shahangian S, et al. Good laboratory practices for molecular genetic testing for heritable diseases and conditions. MMWR Recomm Rep. 06. 12. 2009;58(RR-6):1-37. [pmid: 19521335].
225 Grody W, Richards C. Molecular Diagnostic Methods for Genetic Disease; Approved Guideline. MM01-2A. 2006.
226 Wilson J, Zoccoli M, Jacobson J, et al. Verification and Validation of Multiplex Nucleic Acid Assays; Approved Guideline. MM17-A. 28(9):2008.
227 Sahasranaman S, Howard D, Roy S. Clinical pharmacology and pharmacogenetics of thiopurines. [Review] [153 refs]. Eur J Clin Pharmacol. 08. 2008;64(8):753-67. [pmid: 18506437].
228 Hamdan-Khalil R, Gala JL, Allorge D, et al. Identification and functional analysis of two rare allelic variants of the thiopurine S-methyltransferase gene, TPMT*16 and TPMT*19. Biochem Pharmacol. 02. 1. 2005;69(3):525-9. [pmid: 15652243].
229 Garat A, Cauffiez C, Renault N, et al. Characterisation of novel defective thiopurine S-methyltransferase allelic variants. Biochem Pharmacol. 08. 1. 2008;76(3):404-15. [pmid: 18602085].
230 Lindqvist M, Skoglund K, Karlgren A, et al. Explaining TPMT genotype/phenotype discrepancy by haplotyping of TPMT*3A and identification of a novel sequence variant, TPMT*23. Pharmacogenet Genomics. 10. 2007;17(10):891-5. [pmid: 17885628].
231 Kham SK, Soh CK, Liu TC, et al. Thiopurine S-methyltransferase activity in three major Asian populations: a population-based study in Singapore. Eur J Clin Pharmacol. 04. 2008;64(4):373-9. [pmid: 18193212].
232 Sanderson J, Ansari A, Marinaki T, et al. Thiopurine methyltransferase: should it be measured before commencing thiopurine drug therapy?[see comment]. [Review] [80 refs]. Ann Clin Biochem. 07. 2004;41(Pt 4):294-302. [pmid: 15298741].
233 Ford LT, Berg JD. Thiopurine S-methyltransferase (TPMT) assessment prior to starting thiopurine drug treatment; a pharmacogenomic test whose time has come. J Clin Pathol. 2010;63(4):288-95. [pmid: 20354201].
234 Fargher EA, Tricker K, Newman W, et al. Current use of pharmacogenetic testing: a national survey of thiopurine methyltransferase testing prior to azathioprine prescription. J Clin Pharm Ther. 04. 2007;32(2):187-95. [pmid: 17381669].
235 Colombel JF, Ferrari N, Debuysere H, et al. Genotypic analysis of thiopurine S-methyltransferase in patients with Crohn's disease and severe myelosuppression during azathioprine therapy. Gastroenterol. 06. 2000;118(6):1025-30.
236 Payne K, Newman WG, Gurwitz D, et al. TPMT testing in azathioprine: A 'cost-effective use of healthcare resources'?. Personaliz Med. 2009;6(1):103-13.
237 McGovern DP, Travis SP, Duley J, et al. Azathioprine intolerance in patients with IBD may be imidazole-related and is independent of TPMT activity. Gastroenterol. 03. 2002;122(3):838-9.
238 Seidman EG. Clinical use and practical application of TPMT enzyme and 6-mercaptopurine metabolite monitoring in IBD. Rev Gastroenterol Disord. 2003;3(Suppl 1):S30-8-S30-38. [pmid: 12684587].
239 Mardini HE, Arnold GL. Utility of measuring 6-methylmercaptopurine and 6-thioguanine nucleotide levels in managing inflammatory bowel disease patients treated with 6-mercaptopurine in a clinical practice setting. J Clin Gastroenterol. 05. 2003;36(5):390-5. [pmid: 12702978].
240 Reinshagen M, Schutz E, Armstrong VW, et al. 6-thioguanine nucleotide-adapted azathioprine therapy does not lead to higher remission rates than standard therapy in chronic active crohn disease: results from a randomized, controlled, open trial.[see comment]. Clin Chem. 07. 2007;53(7):1306-14. [pmid: 17495015].
241 Goldenberg BA, Rawsthorne P, Bernstein CN. The utility of 6-thioguanine metabolite levels in managing patients with inflammatory bowel disease. Am J Gastroenterol. 09. 2004;99(9):1744-8. [pmid: 15330913].
242 Ioannidis JP, Ntzani EE, Trikalinos TA, et al. Replication validity of genetic association studies. Nat Genet. 11. 2001;29(3):306-9. [pmid: 11600885].
243 Chakravarty K, McDonald H, Pullar T, et al. BSR/BHPR guideline for disease-modifying anti-rheumatic drug (DMARD) therapy in consultation with the British Association of Dermatologists. Rheumatology (Oxford). 06. 2008;47(6):924-5. [pmid: 16940305].
244 Carter MJ, Lobo AJ, Travis SP. Guidelines for the management of inflammatory bowel disease in adults. Gut. 09. 2004;53(Suppl 5):V1-16. [pmid: 15306569].