# Results

## Screening and Inclusion of Records for Key Questions

The PRISMA diagram in Figure 3 depicts the flow of retrieved records through the phases of screening and inclusion. Overall, 1783 records were identified by systematic searches of databases and seven1,40–45 were nominated by the Technical Expert Panel and reviewers. A third level of content expert screening was employed to ensure that laboratory studies identified for key questions 1a, 1b and 1d did not include irrelevant records, as a result of relatively liberal screening at the two prior levels.

Figure 3 PRISMA diagram of record identification, screening and inclusion

* Two records had two primary reasons for exclusion at level III

Figure 3 depicts a PRISMA diagram of record identification, screening, and inclusion. On the left hand side are a vertical row of 4 shaded boxes, top to bottom, Identification, Screening, Eligibility, and Included. In the middle of the figure is a vertical row of 7 boxes. The top box contains the words Records identified through data base searching (n = 1783). An arrow goes down to the next box, Records screened by title and abstract (Level I) (n = 1783). One arrow goes right from that box to a box, Records excluded at Level I (n = 1252). Another arrow goes down to the next box in the column, Full text articles assessed for eligibility (level I) (n = 538). An arrow goes from that box to the next, Records included at Level II (n = 204). An arrow goes from the arrow to that box to a large box on the right, Full text records excluded at level II. Reasons: (bullet list) Editorial, review, commentary, letter, news, report or case report (n = 44); Study population was not relevant (n = 159); Language of publication was not English (n = 2); Neither abstract nor full text could be retrieved (n = 11); Other reasons (n = 118). From the Records included at Level II (n = 204) box an arrow goes down to a box, Further full text eligibility assessment for key questions 1a and 1b by content experts (level III). An arrow goes down from that box to another box, Records included at level II (n = 169). From that arrow, another arrow goes right to a box, Full text records excluded at level II. Reasons: (bullet list) No direct pre-analytic data of relevance (n = 32); Non-original data (n = 1); No proficiency, reproducibility and precision data (n = 4*). From the Records included at level III box an arrow goes down to the bottom box, Records included in the report (n = 136 records of 115 unique studies). On either side of that box, and connected by an arrow that goes over the middle box, are two boxes. The box on the left is Studies included in quantitative syntheses (n = 45), and the box on the right is Eligible records not reporting relevant data for any key question (n = 33). On the bottom right is the explanation for the asterix, Two records had two primary reasons for exclusion at level III.

Studies that were reported in more than one included record are listed in Table 7. We identified one of these records as the primary report and others as companion papers, however, where applicable, data from both were used in evidence syntheses.

Table 7 Primary records with companion reports passing level III screen

Primary record | Companion record(s)
Palmieri, 2007^47^ | Palmieri, 2006^69^
Winter, 2007^70^ | Winter, 2007^71^
Gisbert, 2006^72^ | Gisbert, 2007^73^
Lindqvist, 2006^49^ | Hindorf, 2006^74^, Hindorf, 2005^75^
Heneghan, 2006^76^ | Heneghan, 2003^77^
Hindorf, 2006^50^ | Hindorf, 2006^78^
Czaja, 2006^79^ | Czaja, 2004^80^
Gearry, 2004^81^ | Gearry, 2003^82^
Winter, 2004^83^ | Winter, 2004^84^
Derijks, 2004^54^ | Derijks, 2003^85^
Marinaki, 2004^86^ | Ansari, 2003^87^
Campbell, 2002^58^ | Campbell, 2002^88^
Black, 1998^89^ | Black, 1998^90^
Stolk, 1998^91^ | Stolk, 1996^92^
Snow, 1995^93^ | Snow, 1994^94^
Kerstens, 1995^95^ | Kerstens, 1992^96^
Walsh, 2008^97^ | Walsh, 2008^98^
Schmeling, 2007^99^ | Schmeling, 2007^100^
Ansari, 2004^62^ | Ansari, 2004^101^
Colletti, 2009^45^ | Colletti, 2006^60^
Xin, 2005^102^ | Xin, 2005^103^

One companion record was considered primary paper for key question 1b74

For 33 of 169 included records, extractable data were not available (Table 8).

Table 8 Distribution of records by key questions

Key question | Total number of studies | Full text records | Abstracts | Eligible studies not reporting relevant data | Studies for which (some or all) data were received from authors
1a | 35^102,104–137^ | 33^102,104–135^ | 2^136,137^ | 0 | 0
1b | 36,74,106–108,111–116,118,121,124,128,131,135,136,138–156 | 33^74,106–108,111–116,118,121,124,128,131,135,138–154^ | 3^136,155,156^ | 3^139,141,149^ | 0
1c | 24^1,46^,49– 53,56,59,70,93,99,157– 168 | 20^1,46^,49– 53,56,59,70,93,157– 163,167,168 | 4^99,164–166^ | 5^99,164–166,168^ | 5^51–53,56,59^
1d | 0 | NA | NA | NA | NA
2 | 1^1^ | 1^1^ | 0 | 0 | 0
3a | 2^1,45^ | 2^1,45^ | 0 | 1^45^ | 1^1^
3b | 3^1,45,169^ | 3^1,45,169^ | 0 | 1^45^ | 0
3c TPMT allelic determination | 49^1,46–54,57–59,61,63,64,67,70,76,81,86,89,93,99,157,162, 165,170–191^ | 34^1,46–54,57–59,70,76,81,86,89,93,157,162,170–180,190,191^ | 15^61,63,64,67,99,165,181–189^ | 15^49,58,63,64,67,76, 162,165,178^,183– 185,187–189 | 5^46–48,52,54,57^
3c TPMT enzymatic activity | 36^46,49–53,55,58,59,62,65,68,70,72,79,91,93,95,97,119,157,161,162,165,192–203^ | 26^46^,49– 53,55,58,59,70,72,79,91,93,95,119,157,161,162,192–197,203 | 10^62,65,68,97,165,198–202^ | 20^46,49,55,58,59,62,65,68,95,97,119,162,165,194,198–203^ | 4^50–53^
4 | 11^40,83,204–212^ | 11^40,83,204–212^ | 0 | 0 | 0

Overall across key questions
Companion records (N=21) | 60,69,71,73,75,77,78,80,82,84,85,87,88,90,92,94,96,98,100,101,103
Studies contributing to the evidence base (N=115) | 1, 46–54, 56, 57, 59, 61, 70, 72, 74, 79, 81, 83, 86, 89, 91, 93, 99, 102, 104–138, 140, 142–148, 150–163, 167, 169–177, 179–182, 186, 190–193, 195–197, 204–212 One companion record was considered unique paper for key question 1b74
Included records that did not report relevant data N=33 | 45,55,58,62–65,67,68,76,95,97,139,141,149,164–166,168,178,183–185,187–189,194,198–203

Abbreviations: NA = not applicable; TPMT = thiopurine methyltransferase

We contacted authors of 24 records requesting additional data or seeking data clarification,1,46–68 and additional data received were incorporated in evidence syntheses.

One hundred and thirty six records associated with 115 unique studies addressing the key questions were included in this systematic review. Additional individual study data and quality assessment are presented in Appendix C. Forty-five studies contributed to meta-analyses and the remaining were included in qualitative syntheses of evidence. No record was identified that answered Key Questions 1d (Table 8).

### Key Question 1a In terms of the analytical performance characteristics of enzymatic measurement of TPMT activity and determination of TPMT allelic polymorphisms, what are the preanalytical requirements for enzymatic measurement of TPMT and determination of TPMT allelic polymorphisms? (e.g. specimen types and collection procedures, lab transportation, interference of coadministered drugs, patient preparation and identification etc.)

A total of 35 studies reported data relevant to answer this key question, all in relation to enzymatic analysis of TPMT activity (Table 8). No evidence was available regarding preanalytical performance characteristics for determination of TPMT allelic polymorphisms. Genotyping is most commonly performed by using the restriction fragment length polymorphism (RFLP) technique, polymerase chain reaction (PCR), or direct sequencing.

Stability. Thirteen studies assessing the stability of TPMT enzyme activity are summarized in Table 9.^108,115,116,118,121,124,127–129,131,134,136,137^ Two studies were conducted in the USA134,136, and eleven in Europe.108,115,116,118,121,124,127–129,131,137 TPMT stability was assessed at room temperature, 4°C; −20°C, −21°C, −23°C, −25°C, −30°C, −70°C, −80°C and −85°C. Time periods from a few hours to 16 months were studied.

Table 9 Stability of TPMT enzymatic activity

Storage temperature | Sample | Storage time, anticoagulant study reference | Stability
Room temperature | Whole blood | 24 h, heparin134 36 h, EDTA108 3 days, heparin121,* 4 days, heparin127 5 days, heparin118 6 days, EDTA124 7 days, heparin121,* | Stable
| Whole blood | 72 h, EDTA137 | 25% +/− 6% decrease in 24 hours
4°C | Whole blood | 24 h, heparin134 4 days, heparin127 6 days, EDTA124,* 8 days, unspecified anticoagulant136 | Stable
−20°C to −30°C | RBC lysate | 7 days116 21 days115 3 month108 Several month124 | Stable
| RBC lysate | 3 month128 | 7% decrease
−70°C to −80°C | RBC lysate | Few days129,131 25 days116 | Stable
| RBC lysate | 16 month128 | 15% decrease

Notes:

* Control blood was stable for 7 days. Leukemia patient blood was stable for 3 days, and the median activity showed a small but statistically significant decrease after 6 days.

Abbreviations: EDTA = ethylene diamine tetra-acetic acid; RBC = red blood cell; TPMT = thiopurine methyltransferase.

TPMT was found to be stable at room temperature for a maximum of seven days in control blood samples, while in a case of acute lymphocytic leukemia, patient blood TPMT was stable for three days.121 At −20°C, TPMT was stable for up to three months. Four studies of storage at −80°C showed that TPMT was stable from a minimum of a few days to 25 days,116,129,131 but TPMT activity decreased by 15 percent after 16 months of storage.116 Repeated freeze-thaw cycles of the red blood cell (RBC) lysate were reported to result in a 16.2 percent decrease in activity.115 However, the decrease was not statistically significant after three cycles (initial values: 9.2, 11.7, and 16.5 U/mL RBCs; final values: 8.1, 9.8, and 14.3 U/mL RBCs). TPMT activity was stable in six blood samples shipped via regular mail, and received two to seven days post sampling (coefficient of variance, 5.6 percent).121

Gender. Eighteen studies evaluated gender-related differences in TPMT activity (Table 10).106,107,110–113,116,117,122,124,125,127–129,131,133–135 Seventeen studies reported the TPMT activity in RBCs and one in renal tissue.133 In 16 studies, no significant differences associated with gender were found in TPMT activity.106,107,110–113,116,117,122,124,125,127,128,131,134,135 One study reported TPMT values to be higher for males in Caucasian and mixed-race groups (30 U/g Hb in females versus 38 U/g Hb in males, and 33 U/g Hb in females versus 39 U/g Hb in males, respectively, for Caucasian and mixed race groups).129 TPMT values in renal tissue were 10 percent higher in males than in females.133 Fifteen studies reported TPMT values, whereas three studies stated only the outcomes of comparisons.107,122,127

Table 10 Gender related differences in TPMT enzymatic activity

Study | Male | Female | Significance
Hindorf 2004^111^ | 12.9 (range, 0.2–24.6) U/mL RBCs (n=607) | 12.7 (range, 0.4–25.4) U/mL RBCs (n=544) | p = 0.08
Weinshilboum 1978^134^ | 10.0 ± 2.3 U/mL RBCs (n = 37) | 10.4 ± 2.5 U/mL RBCs (n = 36)
Tinel 1991^131^ | 14.6 ± 6.7 U/mL RBCs (n=119) | 16.8 ± 7.7 U/mL RBCs (n=184)
Jacqz-Aigrain 1994^128^ | 19.6 ± 4.9 U/mL RBC (n=134) | 18.9± 4.9 U/mL RBC (n=166)
Kroplin 1998^124^ | 38.8 nmol 6-MTG/h/g Hb (n=117) | 36.9 nmol 6-MTG/h/g Hb (n=82)
Keizer- Garritsen 2003^116^ | 15,8± 6,4 pmol/h/107 RBCs (n=59) | 15,1± 4,8 pmol/h/107 RBCs (n=44)
Ganiere- Monteil 2004^113^ | Adults: 19.55± 4.25 U/mL RBCs (n= 229) Children: 18.34±4.21 U/mL RBCs (n=97) | Adults: 18.61±3.59 U/mL RBCs. (n=75) Children: 18.87±3.98 U/mL RBCs (n=50) | Adults: p=0.057. Children: p=0.310
Ford 2004^112^ | Mean and median TPMT activities: 34 and 34 nmol 6- MTG/h/g Hb (n=469) | Mean and median TPMT activities: 33 and 32 nmol 6- MTG/h/g Hb (n=531) | No significant difference
Zhang 2007^106^ | Wild type Healthy: (n=155) 17.05±3.12 U/ml RBCs Heterozygous Healthy: (n=4)7.50±1.58 U/ml RBCs | Wild type Healthy: (n=86) 15.90±2.87 U/ml RBCs. Heterozygous Healthy: (n=3) 8.17±1.30 U/ml RBCs | p=0.01
Zhang 2006^135^ | 12,36 U/mL RBCs (n=5) | 13,16 U/mL RBCs (n=14)
Chocair 1993^129^ | Caucasians: (n = 21) 38 U/g Hb Black: (n = 24) 38 U/g Hb Mixed-race: (n = 19) 39 U/g Hb Japanese: (n = 11) 37 U/g Hb | Caucasians: (n = 12) 30 U/g Hb Black: (n = 15) 36.5 U/g Hb Mixed-race: (n = 11) 33 U/g Hb Japanese: (n = 21) 38 U/g Hb
Micheli 1997^125^ | Adults (20–59 y): (n=7) 21 ± 5 U/g Hb Children (1–14y): (n = 6) 23 ± 5.8 U/g Hb | Adults (20–59 y): (n=7) 15± 8 U/g Hb Children (1–14y): (n = 2) 18.21 U/g Hb
Menor 2002^117^ | 19.7 - 6.2 U/mL RBCs (n=1671) | 19.5 - 6.1 U/mL RBCs (n=1873)
Brouwer 2005^110^ | ALL patients: Median TPMT: 12.4 (range 1.7–30.7) pmol/hr/10^7^ RBCs (n=116) | ALL patients: Median TPMT: 12.8 (range 5.8–30.4) pmol/hr/10^7^ RBCs (n=57) | No significant difference for ALL patients (p = 0.841)
Oselin 2006^107^ | n=52 | n=47 | No significant difference TPMT activity: 21.5 to 129.6 ng/h/mL RBCs
Lennard 1994^127^ | In children, boys versus girls TPMT activity for the entire group (n=100) not significantly different (p > 0.25, Mann-Whitney). High TPMT activity group (n=100) boys versus girls not significantly different (p=0.8)
Alves 2001^122^ | (n=76) | (n=67) | No statistically significant association (p = 0.796, ANOVA).
Lee 1982^133^ | Renal cell carcinoma patients 232 ± 9 U/g tissue or 4.24 ± 0.15 U/mg protein (n=37 ) | Renal cell carcinoma patients 210 ± 21 U/g of tissue or 3.93 ± 0.4 U/mg of protein (n=14) | No significant differences. Imbalance in sample numbers likely due to the 2:1 male:female incidence of renal cell carcinoma.

Abbreviations: 6-MTG = 6-methylthioguanine ALL = acute lymphoblastic leukemia; ANOVA = analysis of covariance; g = gram; mL RBCs = milliliter of red blood cells; p = probability; pmol = picomole; TPMT = thiopurine methyltransferase; U = Unit = nanomole of product per hour

Age. Ten studies investigated variation of TPMT activity with age (Table 11)104,110,111,113,116,123,125,131,133,135 In eight studies TPMT activity was analyzed in RBCs, while one study examined each of renal tissue133 and lymphocytes.123 Only a single study reported a statistically significant difference in TPMT activities between adults and children (12.0 U/mL RBCs in children and teenagers, versus 12.9 U/mL RBCs in adults; p less than 0.001).111

Table 11 Effect of age on TPMT enzymatic activity

Study | Children (<20 years) | Adults (>20 years) | Significance
Hindorf 2004^111^ | 12.0 (range 0.6–25.4) U/mL RBCs (n = 192, <15 y) | 12.9 (range 0.2 – 24.6) U/mL RBCs (n = 959, median age 33.4 y) | p < 0.001
Tinel 1991^131^ | | 14.5 ± 6.7 U/mL RBCs (n = 175, 20–40 y; 16.7 ± 7.6 U/mL RBCs (n = 128) ages from 40 to 60 years. | No significant difference
Ganiere- Monteil 2004^113^ | 18.49 ± 4.13 U/mL RBCs. range: 8.25–30.0 U/mL RBCs (n = 165) | 19.34 ± 4.09 U/mL RBCs range: 0.43–30.38 U/mL RBCs (n = 304) | p = 0.310; no significant difference
Zhang 2006^135^ | | 14.38 U/mL RBCs (22 – 38 y, n = 8) 11.90 U/mL RBCs for age 40–59, n = 11. 12.95 (SD, 3.07) U/mL RBCs entire sample | No significant difference
Micheli 1997^125^ | 22 ± 5 U/mL RBCs (1–14 y, n = 8) | 18 ± 7 U/mL RBC (20–59 y, n=14) | No significant difference
Brouwer 2005^110^ | 2–31 U/mL RBCs Patients with ALL, at diagnosis (5.9 ± 4.1 y, n = 173) | | TPMT activity not correlated with age.
Keizer- Garritsen 2003^116^ | TPMT data various ages. Children, young adults (n=103) | | No significant correlation between TPMT activity and age among children and young adults.
Gisbert 2007^104^ | | 40 ± 16 y (n = 14,545) | No significant correlation between TPMT activity and age
Lee 1982^133^ | | renal TPMT [average 225 ± 9 U/g of tissue (n = 51) | No significant correlation of patient age with TPMT activity with patient age. Correlation coefficients = 0.04 for all samples.
Coulthard 1998^123^ | 0.24 nU/mg lymphocytes Range: 0.1 and 0.76 nU/mg protein 11 months to 15.5 y (n = 35) | 0.16 nU/mg lymphocytes Range: 0.04–0.86 nU/mg protein 16 – 77 y (n = 37) | No significant correlation between TPMT activity and age

Abbreviations: ALL = acute lymphoblastic leukemia; g = gram; mg = milligram; mL RBCs = milliliter of red blood cells; nU = nanoUnit; p = probability; pmol = picomole; TPMT = thiopurine methyltransferase; U = Unit = nanomole per hour

Drugs. Ten studies evaluated the influence of drugs on TPMT activity in blood (Table 12).102,104,105,110,114,117,119,120,128,131 Four studies were conducted in vitro.102,110,114,128 The following drugs were studied: 5-aminosalycilate102,104, sulfasalazine102,114,122, mesalazine105,122, azathioprine105,117, mesalamine58, ac-5-aminosalicylate102, syringic acid128, prednisone128, prednisolone128, 6-methylprednisolone128, cyclophosphamide128, methotrexate110,128, trimethoprim-sulphamethoxazole128, SKF 525-A131, 3,4-dimethoxy-5-hydroxybenzoic acid131, trimethoprim110, vincristine110, dexamethasone110, and L-asparaginase.110 Two studies reported significant inhibition. 3,4-dimethoxy-5-hydroxybenzoic acid decreased TPMT activity by 97 percent in vitro.131 One in vitro study showed concentration-dependent inhibition of TPMT from 11 to 55 percent, in the presence of 80 to 640 mol/L sulfasalazine.114 One study reported 147 to 148 percent stimulation of TPMT activity in vitro by methotrexate and trimethoprim.110 Interestingly, another study of methotrexate in vitro found no effect.116 The rest of the studies reported no significant inhibition by any of the drugs studied.

Table 12 Effects of drugs on TPMT enzymatic activity

Study | Drug ID | Effect on TPMT activity
Tinel 1991^131^ | SKF 525-A | None
Tinel 1991^131^ | 3,4-dimethoxy-5- hydroxybenzoic acid | Decreased by 97%
Dewit 2002^120^ | Acetylated metabolite of 5-aminosalicylic acid, with either sulfasalazine or mesalazine. | No significant change after aminosalicylate withdrawal. TPMT activity before withdrawal of aminosalicylate: whole group: 12.29 U/mL RBCs (range 8.25±16.85); sulfasalazine subgroup: 12.14 U/mL RBCs; mesalazine subgroup 12.43 U/mL RBCs. TPMT activity after aminosalicylate withdrawal: whole group: 11.41 U/mL RBCs (7.3±14.5) (p=0.245, not significant); sulfasalazine subgroup: 11.43 U/mL RBCs; mesalazine subgroup: 11.39 U/mL RBCs.
Dilger 2007^105^ | Azathioprine versus mesalazine | No significant differences between patients on azathioprine compared with those on mesalazine, at baseline or at any further visit.
Gisbert 2007^104^ | 5-aminosalycilates | No differences between patients on azathioprine or 5- aminosalicylates versus controls. Azathioprine: no treatment 20.7 U/mL RBCs versus treatment 21.2 U/mL RBCs 5-aminosalycilates: no treatment 20.9 U/mL RBCs versus treatment 21.2 U/mL RBCs
Dubinsky 2002^119^ | Mesalamine | No differences between patients on mesalamine medications versus controls (median 32.4 (range 14.7- 49.2) ELISA units vs. 31.8 (15.3–49.1 ELISA units)
Menor 2002^117^ | azathioprine | No significant difference between patients on azathioprine versus no treatment 19.9 ± 6.0 U/mL RBCs versus 19.7±5.8 U/mL RBCs
Xin 2005^102^ | sulfasalazine, 5-aminosalicylate, Ac-5-aminosalicylate | No significant effects in vitro. IC50s: Sulfasalazine: 9.4 (±3.1) μM 5-aminosalicylate: 236 (±55) μM Ac-5-aminosalicylate: 73 (±20) μM
Jacqz- Aigrain 1994^128^ | syringic acid, prednisone, prednisolone, 6- methylprednisolone, cyclophosphamide, methotrexate, trimethoprim sulphamethoxazole | No significant effect in vitro. Residual TPMT activity was always more than 70% of control activity.
Shipkova 2004^114^ | sulfasalazine | Significant, concentration-dependent inhibition 11% for 80 μM to 45% for 640 μM sulfasalazine.
Brouwer, 2005^110^ | methotrexate, trimethoprim, vincristine, dexamethasone, L-asparaginase | TPMT activity significantly increased in vitro. 2.4 μM trimethoprim: 148% 0.01 μM methotrexate: 147%. Vincristine, dexamethasone and L-asparaginase had nonsignificant inhibitory effects on TPMT activity.

Abbreviations: IC50 = concentration of inhibitor at which enzyme activity is 50 percent of uninhibited activity; mL RBCs = milliliter of red blood cells; p = probability; TPMT = thiopurine methyltransferase; U = Unit = nanomole per hour; μM = micromoles per liter.

Race. Two studies of TPMT activity differences among different races are summarized in Table 13.^109,129^ No significant differences among studied races (Caucasians, blacks, Japanese, mixed races) were found.109,129

Table 13 Variation of TPMT activity with race

Study | Population | TPMT activity (range) (U/mL RBCs)
Heckmann 2005^109^ | Black (n=50) 8.75 | 8.75 (6.5–10.1)
Heckmann 2005^109^ | Mixed race (n=50) | 10.15 (8.7–11.3)
Heckmann 2005^109^ | Caucasian (n=15) | 13.40 (10.9–15.1)
Chocair 1993^129^ | Black (n=39) | 37 (13–84)
Chocair 1993^129^ | Mixed race (n=30) | 36.5 (14–65)
Chocair 1993^129^ | Japanese (n=32) | 37.5 (29–48) **
Chocair 1993^129^ | Caucasian (n=33) | 32 (15–54) **

Note:

** (p<0.04)

Abbreviations: n = number in group; RBCs = red blood cells; TPMT = thiopurine methyltransferase; U = Unit = nanomole per hour.

Hematocrit. The effect of hematocrit on TPMT activity was measured in three studies.117,126,104 One study proposed a decrease of TPMT activity by seven percent (range 1.2 percent to 12.0 percent) when comparing the high and low hematocrit levels among 12 participants.126 They studied TPMT activity between erythrocyte fractions of 0.1 and 0.5 and reported the slopes to be significantly different from zero (p ranging from 0.02 to 0.0001). A single study reported young RBCs to have TPMT activity 8.8 units higher than old RBCs (Wilcoxon median difference 8.8 units (95 percent CI 7.2 to 10.8, p=0.006).121 Among 10 participants, TPMT activities in the 60 percent, 63 percent, 66 percent and 69 percent gradients were analysed and the TPMT activities in each gradients differed (p less than 0.001). Another study described no hematocrit dependant difference in TPMT activity.104

Morbidities. Two studies104,106 evaluated the effect of morbidities on TPMT activity (Table 14). Inflammatory bowel disease (ulcerative colitis, Crohn disease, and indeterminate colitis), autoimmune hepatitis, multiple sclerosis, myasthenia gravis, pemphigus and chronic renal failure were studied. Statistically significant differences (p less than 0.001) in TPMT activity were observed among some disease groups, such as inflammatory bowel disease, autoimmune hepatitis, multiple sclerosis, myasthenia gravis, and pemphigus.104 Patients with chronic renal failure had almost double the TPMT activity compared with the healthy control before hemodialysis (33.88 ± 12.33 U/mL RBCs versus 16.03 ± 4.16 U/mL RBCs).106 Posthemodialysis TPMT activity levels were comparable to patients without renal failure.

Table 14 TPMT activity in various disease groups

Study | Population | TPMT activity (U/mL RBCs)
Gisbert 2007^104^ | All study participants | 20.1 ± 6 (Range 0–46.4)
| Inflammatory bowel disease (n=7046) | 20.4 ± 6
| Autoimmune hepatitis (n=359) | 21.5 ± 6
| Multiple sclerosis (n=814) | 18.4 ± 6
| Myasthenia gravis (n=344) | 20.9 ± 6
| Pemphigus (n=133) | 21.1 ± 6
Zhang 2007^106^ | Healthy control (n=241) | 16.03 ± 4.16
| Chronic renal failure (n=30): before hemodialysis | 33.88 ± 12.33
| Chronic renal failure (n=30): after hemodialysis | 17.89 ± 5.24

Abbreviations: n = number in group; RBCs = red blood cells; TPMT = thiopurine methyltransferase; U = Unit = nanomole per hour.

Key points. TPMT is a stable enzyme that apparently can be stored for up to seven days at room temperature, and up to three months at −30°C. However, further research is required to confirm this.

Age and gender do not appear to affect TPMT activity. Furthermore, although the current data does not demonstrate racial differences between TPMT activities, further research is required to confirm this.

A number of drugs were studied for their effect on TPMT activity, including 5-aminosalycilate, sulfasalazine, mesalazine, azathioprine, mesalamine, ac-5-aminosalicylate, syringic acid, prednisone, prednisolone, 6-methylprednisolone, cyclophosphamide, methotrexate, trimethoprim-sulphamethoxazole, SKF 525-A, 3,4-dimethoxy-5-hydroxybenzoic acid, trimethoprim, vincristine, dexamethasone, L-asparaginase. Studies showing potentially clinically significant effects were conducted in vitro, and therefore their in vivo influence on TPMT activity remains unknown.

In patients with renal failure, TPMT activity is elevated prior to hemodialysis, and returns to normal levels following hemodialysis.

No studies were identified that addressed preanalytic variables for TPMT genotyping.

### Key Question 1b In terms of the analytical performance characteristics of enzymatic measurement of TPMT activity and determination of TPMT allelic polymorphisms, what are the within and between laboratory precision and reproducibility of the available methods of enzymatic measurement of TPMT and determination of TPMT allelic polymorphisms (proficiency testing)?

Thirty-three studies reported information relevant to question 1b enzymatic measurement.74,106–108,111–116,118,121,124,128,131,135,136,138,140,142–148,150–156 Detailed information is available in Appendix C. Two studies were conducted in North-America,136,155 three studies in China,106,135,154 and the remaining 28 in Europe.

TPMT enzymatic activity is usually determined by measuring the formation of 6-methyl mercaptopurine (6-MMP) from 6-mercaptopurine (6-MP), with S-adenosyl-L-methionine (SAM) as the methyl donor. This was originally described by Weinshilboum et al, who used radiolabelled SAM.134 More recently, 6-MMP has also been measured using high performance liquid chromatography (HPLC). TPMT is prevalent in many tissue types, but in clinical practice it is normally measured in red blood cells (RBCs).

Nine studies used radiolabelled SAM for TPMT assays.74,111,138,140,154,156 The reported inter-assay coefficient of variation (CV) ranged from 0.51 to 8.4 percent. The intra-assay CV ranged from 0.72 to 6.8 percent. One study reported regression values as y = 0.72x + 0.43 = 0.75, where x represents the value for first estimate of TPMT activity and y the value for the second estimate.131 This result indicates high reproducibility. One study reported a 95 percent confidence interval as 13.94 to 14.88 U/mL RBCs for a high TPMT enzyme sample and 8.07 to 8.78 U/mL RBCs for an intermediate TPMT sample.148 One study144 used thin layer chromatography and quantitative scanning to measure TPMT activity, with 6-MP as a substrate, and radiolabelled SAM as cosubstrate. The day to day variance was 8.5±1.7 percent.

Seventeen studies used an HPLC assay to determine 6-MMP.106,108,113–116,118,121,135,143,145,146,150–153,155 The inter-assay CV ranged from 0.2 to nine percent and the intra-assay CV ranged from zero to 9.5 percent. One study reported the assay to be accurate, and highly reproducible when the samples were kept at −80°C for up to 25 days.116 Another study reported 4 percent precision and 96 to 103 percent accuracy.107 However, the authors did not clearly describe how the variability was measured. Five studies used an HPLC method to measure 6-methylthioguanine (6-MTG) formed using 6-thioguanine (6-TG) as a substrate,112,124,136,142,147 and reported CVs from two to five percent for intra-assay, and from four to 10 percent for inter-assay performance.

Two studies measured the between laboratory precision and reproducibility.113,126 Two labs in France, Laboratoire de Pharmacologie Pediatrique et Pharmacogenetique (Hospital Robert Debre, France) and Laboratoire de Pharmacologie (Hotel-Dieu, France) studied HPLC precision with 6-MMP in erythrocyte lysate (25, 75, 125 ng/mL). The intra-day and inter-days CV values were 1.7 to 4.3 percent, and 0.8 to six percent respectively, for six samples. Inter-assay CV values were 5.8 percent for 20 samples, and 5.2 percent for five samples of quality control blood. Klemetsdal et al (Department of Pharmacology, Institute of Medical Biology, University of Tromso, Norway) compared RBC TPMT activity in five samples with those measured in Dr. Weinshilboum’s laboratory at the Mayo Clinic (Rochester, USA), finding CV values of 1.8 percent to 2.6 percent for 20 analyses.126

Overall, no obvious trend, depending on time or study characteristics, was observed between studies reporting lower versus those reporting higher accuracy and reproducibility.

No study was found that specifically investigated the accuracy and precision of TPMT allelic polymorphism determination. However, three studies compared different genotyping methods to one other.105,139,141 One group developed a novel multiplex assay using matrix-assisted laser desorption/ionization, with a time-of-flight mass spectrometer (MALDI-TOF mass spectrometry) based on Sequenom iPLEX technology.139 All genotypes for 586 samples were 100 percent concordant with the results from a previous denaturing HPLC genotyping assay. The new method was accurate, with 100 percent agreement for duplicate analyses. The other study used TaqMan® 5′ nuclease assay for genotyping.105 Fifty samples genotyped by denaturing HPLC direct sequencing were in 100 percent concordance with TaqMan®.213 In the third study, a microchip based method that includes PCR, RFLP and capillary electrophoresis in a single platform was developed and tested. 100 percent concordance was reported for 80 patients, comparing the microchip method with both the conventional RFLP assay and the commercial TaqMan® assay.141

Key points. The various methods used to determine TPMT enzymatic activity are based on a method developed by Weinshilboum et al.134 While the enzymatic reaction has remained relatively unchanged, with a few minor adjustments, the method of product detection has evolved from radiolabel detection to HPLC.

Both detection techniques produce reliable results, with intra- and inter-assay CVs of less than 10 percent.

Choice of TPMT substrate, 6-MP or 6-TG, does not appear to affect the precision of the assay significantly; however, 6-MP appears to be more widely used.

Three studies have compared MALDI-TOF, TaqMan® and microchip assays with denaturing HPLC and RFLP, and demonstrated 100 percent concordance in genotypes.

### Key Question 1c What is the diagnostic sensitivity and specificity of TPMT allelic polymorphism measurement compared to the measurement of TPMT enzymatic activity in correctly identifying chronic autoimmune disease patients eligible for thiopurine therapy with low or absent TPMT enzymatic activity? How do effect modifiers (e.g. underlying disease prevalence and severity, different activity thresholds, Hardy-Weinberg equilibrium, number and types of alleles tested) explain any observed heterogeneity in sensitivity and specificity?

(see Results Update)

Nineteen studies reported relevant data on testing of variable numbers and types of variant thiopurine methyl transferase alleles (Table 8). For certain combinations of alleles tested, only single studies provided data, and for those combinations, evidence was considered insufficient for any meaningful syntheses.159,160,163 One early study undertaken in 1993 did not report the specific variant alleles that were tested.93 In a sensitivity analysis we assumed the common TPMT *3A, *3B, *3C alleles were tested in this study, in keeping with the early date of publication when fewer alleles were being identified and tested.

Characteristics of included studies and risk of bias. Study characteristics are summarized in Table 15.

Table 15 Characteristics of studies of diagnostic accuracy of TPMT genetic testing compared with TPMT enzymatic activity

Characteristic | | Number of studies | References
Study Design
| Cross-Sectional | 11 | 1,50,53,56,59,70,93,160–162,167
| NonRandomized Intervention Study | 1 | 46
| Prospective Observational | 4 | 49,51,158,159
| Randomized Controlled Trial | 1 | 52
| Retrospective Review of Records | 2 | 157,163
Chronic Autoimmune Disease
| AntiNeutrophil Cytoplasmic Antibody Associated Vasculitis | 1 | 157
| Autoimmune Dermatologic Conditions | 1 | 93
| Autoimmune Hepatitis | 2 | 162,167
| Inflammatory Bowel Disease | 14 | 1,46,49–52,56,59,70,158–161,163
| Systemic Lupus Erythematosus | 1 | 53
Allelic Variants Tested
| TPMT*2, *3A, *3B, * 3C | 7 | 1,51–53,59,70,157
| TPMT*2, *3A, *3B, *3C, *3D | 1 | 163
| TPMT*2, *3A, *3C | 3 | 56,158,161
| TPMT*3A, *3B, *3C | 2 | 46,162
| TPMT*3A, *3B, *3C, *3D | 1 | 159
| TPMT*2, *3A, *3B, *3C, *3D, *4, *5, *6, *7, *8 | 1 | 160
| TPMT*2, *3A, *3B, *3C, *3D, *4, *5, *6, *7, *8, 10, *14, *15 | 3 | 49,167,214
| Not Reported | 1 | 93
TPMT Assay Type
| High Performance Liquid Chromatography | 7 | 1,51,53,59,157,163,167
| Mass Spectrometry | 2 | 46,70
| Radioassay | 10 | 49,50,52,56,93,158–162
Genotyping Method
| Denatured High Performance Liquid Chromatography | 1 | 163
| Polymerase Chain Reaction | 12 | 1,51–53,56,59,70,157–159,161,162
| Pyrosequencing | 4 | 49,50,160,167
| Not Reported | 2 | 46,93
Age Group
| Adults | 11 | 1,46,49,50,52,93,158,159,161,163,167
| Mixed | 4 | 51,59,160,162
| Not Reported | 4 | 53,56,70,157
Setting
| Outpatient Specialty Clinics | 9 | 1,46,49,51,56,59,161–163
| Inpatients, and Outpatient Specialty Clinic | 1 | 158
| Not Reported | 8 | 50,52,70,93,157,159,160,167,214
Region
| Asia | 1 | 53
| Europe | 14 | 1,46,49–52,56,59,70,159,160,162,163,167
| North America | 1 | 93
| Oceania | 1 | 158
| Not Reported | 2 | 157,161
Risk of Bias
| Fair | 12 | 1,46,49,50,52,56,70,157,159,161,163,167
| Poor | 7 | 51,53,59,93,158,160,162

Abbreviations: TPMT = thiopurine methyltransferase

Over 50 percent of included studies were cross-sectional, and 21 percent were of prospective observational design. Studies did not specifically examine diagnostic accuracy of genetic testing with the TPMT enzymatic activity test as the reference standard, so we designated the activity test to be the reference standard and genotyping to be the index test. Over 75 percent of studies were conducted in patients with inflammatory bowel disease (IBD). Most studies used standard TPMT activity cutoffs.

Risk of bias is summarized in Figure 4 with studies grouped according to items of the QUADAS risk of bias scale.35 Only one study clearly reported that genotyping and enzymatic activity measurements were not influenced by prior knowledge of the other test result.162 Sixty-three percent of studies were considered to be of fair quality and the rest were rated poor.

Figure 4 Risk of bias of studies of diagnostic accuracy of TPMT genetic testing compared with TPMT enzymatic activity

Figure 4 depicts the risk of bias of studies of diagnostic accuracy of TPMT enzymatic activity in the form of a bar graph. On the bottom, from left to right are the percentages, 0%, 20%, 40%, 60%, 80%, 100%. The results on the bars are, left to right, Yes in black, No in white, and Unclear in shaded gray. The percentages for each question, Yes, to No, to Unclear, are: Representative of patient population? 5, 16, 79; Clearly described I/E criteria? 53, 26, 21; TPMT test accurate for enzymatic activity? 100, 0, 0; All patients or random sample tested for TPMT activity? 68, 5, 26; Activity tested regardless of genotype? 79, 0, 26; Independence of TPMT activity and genotyping tests? 100; Genotyping method clearly described for replication? 89, 11, 0. Activity assay clearly described for replication? 100, 0, 0; Activity test interpretation was blinded to patient genotype? 5, 0, 95; Genotype determination was blinded to patient TPMT activity? 5, 0, 95; Pre-testing clinical data availability typical of practice? 21, 0, 79; Reporting of uninterpretable or equivocal test results? 5, 69, 26; Study withdrawals explained? 58, 42, 0; Deviation from Hardy Weinberg equilibrium tested? 5, 95, 0.

Diagnostic sensitivity and specificity of TPMT genotyping with respect to the enzymatic activity assay as the reference standard are presented below. Diagnostic groups are organized according to the specific set of TPMT variant alleles tested. Insufficient evidence was available for the following sets of single nucleotide polymorphisms (SNPs):

- TPMT *2, *3A, *3B, *3C, *3D, *4, *5, *6, *7, *8^160^
- TPMT *2, *3A, *3B, *3C, *3D163
- TPMT *3A, *3B, *3C, *3D159

As described above in the “Methods” section, when possible, two meta-analyses were considered for each set of variant alleles. In meta-analysis 1, genotypes were dichotomized into noncarriers (or wild types) and carriers (or homozygotes and/or heterozygotes) and phenotypes were dichotomized into normal (or high) and subnormal (or intermediate and/or low and/or absent) enzymatic activities. In meta-analysis 2, we dichotomized genotypes into noncarriers and/or heterozygotes and homozygotes, and phenotype into normal and/or high and/or intermediate and low/absent activities (Table 16).

Table 16 Meta-analyses 1 and 2, for sensitivity and specificity of variant allelic determination to diagnose TPMT enzymatic activity

Meta-analysis 1
| Normal/high activity | Intermediate/low/absent activity | Sensitivity 1 | Specificity 1
Homozygotes and/or heterozygotes | A1 | B1 | B1/(B1+D1) | C1/(C1+A1)
Noncarrier (or Wild types) | C1 | D1 | B1/(B1+D1) | C1/(C1+A1)

Meta-analysis 2
| Normal/high/intermediate activity | Low/absent activity | Sensitivity 2 | Specificity 2
Homozygotes | A2 | B2 | B2/(B2+D2) | C2/(C2+A2)
Noncarrier (or Wild types) and/or heterozygotes | C2 | D2 | B2/(B2+D2) | C2/(C2+A2)

TPMT *2, *3A, *3B, and *3C. These variant alleles were genotyped in seven studies involving 752 participants.1,51–53,59,70,157 In meta-analysis 1, the pooled sensitivity of the carrier genotypes (i.e. homozygosity and heterozygosity) to correctly identify all those patients with subnormal enzymatic activity as determined by activity assays was 70.70 percent (95 percent CI 37.90 percent to 90.50 percent). Risk of bias was not found to be significantly associated with variation in effect estimates. No explanation was identified for this heterogeneity. The pooled specificity of the noncarrier or wild type genotype to correctly identify all of those with normal/high enzymatic activity was 99.90 percent (95 percent CI 97.40 percent to 99.60 percent) (Figure 5).

Figure 5 Meta-analysis 1 of sensitivity and specificity of genotyping TPMT *2, *3A, *3B and *3C, to diagnose TPMT activity

† [underlined: (Homozygotes or heterozygotes with intermediate or low to absent enzymatic activity)] (all with intermediate or low enzymatic activity)

‡ [underlined: (Noncarriers or wild type genotype with normal/high enzymatic activity)] (all with normal or high enzymatic activity)

Figure 5 depicts Meta-analysis 1 of sensitivity and specificity of genotyping TPMT *2, *3A. *3B, and *3C, to diagnose TPMT activity. The figure is divided into three columns with the headings, left to right, Study, Sensitivity† Specificity‡, and Sensitivity & Specificity (95%, CI), with a smaller graph to the right with a line and bullet illustrating the percentages 0%–100%. From left to right the results are, Winter, 2007--11/17 113/113--64/7 (40.4, 83.2) 99.6 (93.4, 100); Stocco, 2004--4/4 23/23--90.0 (32.6, 99.4) 97.9 (74.1, 99.9); von Ahlsen, 2005--5/21 50/50--23.8 (10.3, 46.0) 99.0 (86.2, 99.9); Okada, 2005--3/13 41/42--23.1 (7.6, 52.2) 97.6 (86.2, 99.9); Stocco, 2005--3/3 25/25--87.5 (26.6, 99.3) 98.1 (75.6, 99.9); Stassen, 2009--7/7 101/101--93,8 (46.1, 999.6) 99.5 (92.7, 100); Newman, 2010--35/37 296/296--94.6 (80.8, 98.6) 99.8 (97.0, 100); Pooled--blank--70.7 (37.9, 90.5) 99.0 (97.4, 99.6). On the bottom left of the figure are explanations of the symbols; †Homozygotes or heterozygotes with intermediate or low to absent enzymatic activity (all with intermediate or low enzymatic activity); ‡Noncarriers or wild type genotype with normal/high enzymatic activity (all with normal or high enzymatic activity).

In meta-analysis 2, since only one patient was homozygous for a TPMT allele, only the pooled specificity of noncarrier and heterozygous carrier genotype to correctly identify all those who do not have low or absent enzymatic activities could be calculated. This approached 100 percent (Figure 6).

Figure 6 Meta-analysis 2 of specificity of genotyping TPMT *2, *3A, *3B and *3C, to diagnose TPMT activity

‡ [underlined: (Noncarriers (wild type) and/or heterozygotes with normal/intermediate/high enzymatic activity)] (all with normal, intermediate or high enzymatic activity)

Figure 6 depicts a Meta-analysis 2 of specificity of genotyping TPMT *2, *3A, *3B, and *3C, to diagnose TPMT activity. The figure is divided into three columns with the headings, left to right, Study, Specificity‡, and Specificity (95%, CI), with a smaller graph to the right with a line and bullet illustrating the percentages 0%–100%. From left to right the results are, Winter, 2007--129/129--99.6 (94.2, 100); Stocco, 2004--27/27--98.2 (77.0, 99.9); von Ahlsen, 2005--71/71--99.3 (89.9, 100); Okada, 2005--55/55--99.1 (87.3, 99.9); Stocco, 2005--27/27--98.3 (77.7, 99.9); Stassen, 2009--108/108--99.5 (93.1, 100); Newman, 2010--332/332--99.8 (97.6, 100); Pooled--blank--99.3 (98.1, 99.8). On the bottom left of the figure are explanations of the symbols; ‡Noncarriers (wild type) and/or heterozygotes with normal/intermediate/high enzymatic activity (all with normal or high enzymatic activity).

In further sensitivity analyses, we assumed that studies that specifically tested the alleles TPMT *2, *3A, *3C (see below) also implicitly tested for *3B, because of shared *3B SNP 460G→A, which is one of the two TPMT *3A alleles. We therefore widened meta-analysis 1 and 2 to included the three studies that reported specifically testing for TPMT *2, *3A, *3C as additional sensitivity analyses.56,158,161 Still, only one of a total of 945 patients in nine studies was homozygous for a TPMT variant allele. In the sensitivity meta-analysis 1, the pooled sensitivity of the carrier genotype (i.e. homozygosity and heterozygosity) to correctly identify all those patients with subnormal enzymatic activity as determined by activity assays remained unchanged at 74.00 percent (95 percent CI 48.90 percent to 89.40 percent). Risk of bias was again not found to be significantly associated with variation in effect estimates. The pooled specificity of the noncarrier or wild type genotype to correctly identify all of those with normal/high enzymatic activity was 98.60 percent (95 percent CI 97.10 percent to 99.30 percent) (Figure 7).

Figure 7 Additional meta-analysis 1 of sensitivity and specificity of genotyping TPMT *2, *3A, *3B and *3C, or TPMT *2, *3A and *3C, to diagnose TPMT activity

† [underlined: (Homozygotes or heterozygotes with intermediate or low to absent enzymatic activity)] (all with intermediate or low enzymatic activity)

‡ [underlined: (Noncarriers or wild type genotype with normal/high enzymatic activity)] (all with normal or high enzymatic activity)

Figure 7 depicts Additional meta-analysis 1 of sensitivity and specificity of genotyping TPMT *2, *3A, *3B, and *3C, or TPMT *3A, *3B, and *3C, to diagnose TPMT activity. The figure is divided into three columns with the headings, left to right, Study, Sensitivity† Specificity‡, and Sensitivity Specificity (95%, CI), with a smaller graph to the right with a line and bullet illustrating the percentages 0%–100%. From left to right the results are, Gardiner, 2008--5/9 57/59--55.6 (25.1, 52.3) 96.6 (87.4, 99.2); Ansari, 2002--10/10 30/30--95.5 (55.2, 99.7) 98.4 (78.9, 99.9); Marinaki, 2003--5/5 80/80--91.7 (37.8, 99.50 99.4 (90.0, 100); Winter, 2007--11/17 113/113--64.7 (40.4, 83.2) 99.6 (93.4, 100); Stocco, 2004--4/4 23/23--90.0 (32.6, 99.4) 97.9 (74.1, 99.9); von Ahlsen, 2005--5/21--50/50--23.8 (10.3, 46.0) 99.0 (86.2, 99.9); Okada, 2005--3/13 41/42--23.1 (7.6, 52.2) 97.6 (86.2, 99.9); Stocco, 2005--3/3 25/25--87.5 (26.6, 99.3) 98.1 (75.6, 99.9); Stassen, 2005--7/7 101/101--93,8 (46.1, 99.6) 99.5 (92.7, 100); Newman, 2010--35/37 296/296--94.6 (80.8, 98.6) 99.8 (97.0, 100); Pooled--blank--74.0 (48.9, 89.4) (98.6 (97.1, 99.30). On the lower left are explanations for the symbols: †Homozygotes or heterozygotes with intermediate or low to absent enzymatic activity (all with intermediate or low enzymatic activity); ‡Noncarriers or wild type genotype with normal/high enzymatic activity (all with normal or high enzymatic activity).

In the sensitivity meta-analysis 2, since only one patient was homozygous for a TPMT allele, only the pooled specificity of noncarrier and heterozygous carrier genotype to correctly identify all those who do not have low or absent enzymatic activities could be calculated. This approached 100 percent (Figure 8)

Figure 8 Additional meta-analysis 2 of specificity of genotyping TPMT *2, *3A, *3B and *3C, or TPMT *2, *3A and *3C, to diagnose TPMT activity

‡ [underlined: (Noncarriers (wild type) and/or heterozygotes with normal/intermediate/high enzymatic activity)] (all with normal, intermediate or high enzymatic activity)

Figure 8 depicts Additional meta-analysis 2 of specificity of genotyping TPMT *2, *3A, *3B and *3C, or TPMT *2, *3A and *3C, to diagnose TPMT activity. The figure is divided into three columns with the headings reading left to right: Study, Specificity‡, and Specificity (95% Confidence Interval). From left to right, the results are: Gardiner, 2008--68/68 99.3 (89.5, 100); Ansari, 2002--40/40--98.8 (83.3, 99.9); Winter, 2007--129/129--99.6 (94.4, 100); Marinaki, 2003--85/85--99.4 (91.4, 100); Stocco, 2004--27/27--98.2(77.0, 99.9); Von Ahsen, 2005--71/71--99.3(89.9, 100); Okada, 2005--55/55--99.1 (87.3, 99.9); Stocco, 2005--27/27--98.3 (77.7, 99.9); Stassen, 2009--108/108--99.5 (93.1, 100); Newman, 2010-- 332/332--99.8 (97.6, 100); Pooled--99.3 (98.3, 99.7).

TPMT *2, *3A, and *3C. These variant alleles were genotyped in three studies including 386 patients.56,158,161 In meta-analysis 1, the pooled sensitivity of the carrier genotype (i.e. homozygosity and heterozygosity) to correctly identify all those patients with subnormal enzymatic activity was 82.10 percent (95 percent CI 40.40 percent to 96.90 percent). The pooled specificity of noncarrier or wild type genotypes to correctly identify all those with normal/high enzymatic activity was 97.80 percent (95 percent CI 93.30 percent to 99.30 percent).(Figure 9). This group of studies did not include any homozygous participant; hence only the specificities of noncarrier and heterozygous carrier genotypes to correctly identify all those who do not have low/absent enzymatic activity could be pooled for meta-analysis 2. The pooled estimate approached 100 percent (Figure 10).

Figure 9 Meta-analysis 1 of sensitivity and specificity of genotyping TPMT *2, *3A, and *3C, to diagnose TPMT activity

† [underlined: (Homozygotes or heterozygotes with intermediate or low to absent enzymatic activity)] (all with intermediate or low enzymatic activity)

‡ [underlined: (Noncarriers or wild type genotype with normal/high enzymatic activity)] (all with normal or high enzymatic activity)

Figure 9 depicts a meta-analysis 1 of sensitivity and specificity of genotyping TPMT *2, *3A, and *3C, to diagnose TPMT activity. The figure is divided into three columns with the headings reading left to right: Study; Sensitivity† over the top of Specificity‡, and Sensitivity and Specificity (95% Confidence Interval). The figure is divided into three columns with the headings reading left to right: Study, Sensitivity† and Specificity‡, and Specificity (95% Confidence Interval). From left to right, the results are: Gardiner, 2008-- 5/8--55.6 (25.1, 82.3) and 57/59-- 96.6 (87.4, 99.2); Ansari, 2002-- 10/10 -- 95.5 (55.2, 99.7) and 30/30-- 98.4 (78.9, 99.9). Marinaki, 2003 5/5-- 91.7 (37.8, 99.5) and 80/80-- 99.4 (90.0), 100; Pooled--82.1 (40.4, 96.9) and 97.7 (93.3, 99.3).

Figure 10 Meta-analysis 2 of specificity of genotyping TPMT *2, *3A, and *3C, to diagnose TPMT activity

‡ [underlined: (Noncarriers (wild type) and/or heterozygotes with normal/intermediate/high enzymatic activity)] (all with normal, intermediate or high enzymatic activity)

Figure 10 depicts a meta-analysis 2 of specificity of genotyping TPMT *2, *3A, and *3C, to diagnose TPMT activity. The figure is divided into three columns with the heading reading left to right: Study, Specificity‡, and Specificity (95 percent confidence interval). From left to right, the results are: Gardiner, 2008--68/68--99.3 (89.5, 100); Ansari, 2002--40/40--98.8 (83.3, 99.9);Mazrinaki, 2003--85/85--99.4 (91.4, 100); Pooled results-- 99.2, (96.2, 99.8)

TPMT *3A, *3B, and *3C. These variant alleles were genotyped in two studies that included a total of 245 participants.46,162 In meta-analysis 1, the pooled sensitivity of the carrier genotype (i.e. homozygosity and heterozygosity) to correctly identify all those patients with subnormal enzymatic activity was 71.80 percent (95 percent CI 54.00 percent to 84.60 percent). The pooled specificity of noncarrier or wild type genotypes to correctly identify all those with normal/high enzymatic activity was 97.30 percent (95 percent CI 69.60 percent to 99.80 percent) (Figure 11). In a sensitivity analysis, when we included an early study by Snow et al.,93 a study that did not report variant alleles it tested, under the assumption that it tested TPMT *3A, *3B, *3C, the results remained essentially unchanged for pooled estimates of both sensitivity and specificity (N = 26). Because no homozygous carriers were included, meta-analysis 2 was only possible for specificity of noncarrier and heterozygous carrier genotypes to correctly identify all those who do not have low/absent enzymatic activity. The pooled specificity approached 100 percent.

Figure 11 Meta-analysis 1 of sensitivity and specificity of genotyping TPMT *3A, *3B and *3C, to diagnose TPMT activity

† [underlined: (Homozygotes or heterozygotes with intermediate or low to absent enzymatic activity)] (all with intermediate or low enzymatic activity)

‡ [underlined: (Noncarriers or wild type genotype with normal/high enzymatic activity)] (all with normal or high enzymatic activity)

Figure 11 depicts a meta-analysis of sensitivity and specificity of genotyping TPMT *3A, *3B and *3C, to diagnose TPMT activity. The figure is divided into three columns with the heading reading left to right: Study, Sensitivity† Specificity‡, and Sensitivity and Specificity (95 percent confidence interval). From left to right, the results are: Ansari, 2008-- 17/23 and 168/169--73.9 (52.8, 87.8); Langley, 2002--6/8 and 40/44--66.7 (33.3, 88.9), 90.9 (78.2, 96.5); Pooled--71.8, (54.0, 84.6) and 97.3 (69.6, 99.8).

TPMT *2, *3A, *3B, *3C, *3D, *4, *5, *6, *7, *8, *10, *14, and *15. These variant alleles were genotyped in three studies that included a total of 341 patients of whom seven were homozygous for an SNP.49,50,167 In meta-analysis 1, the pooled sensitivity of the carrier genotype (i.e. homozygosity and heterozygosity) to correctly identify all those patients with subnormal enzymatic activity was 81.30 percent (95 percent CI 59.90 percent to 92.70 percent). The pooled specificity of noncarrier or wild type genotypes to correctly identify all those with normal/high enzymatic activity was 8.50 percent (95 percent CI 96.10 percent to 99.40 percent) (Figure 12). In meta-analysis 2, the sensitivity of the homozygous genotype to correctly identify all patients with low/absent enzymatic activity was 87.10 percent (95 percent CI 44.30 percent to 98.30 percent), and the specificity of noncarrier and heterozygous carrier genotype to correctly identify all those who do not have low/absent enzymatic activity approached 100 percent (Figure 13). No other combinations of variant TPMT alleles were tested.

Figure 12 Meta-analysis 1 of sensitivity and specificity of genotyping TPMT *2, *3A, *3B, *3C, *3D, *4, *5, *6, *7, *8, *10, *14, and *15, to diagnose TPMT activity

† [underlined: (Homozygotes or heterozygotes with intermediate or low to absent enzymatic activity)] (all with intermediate or low enzymatic activity)

‡ [underlined: (Noncarriers or wild type genotype with normal/high enzymatic activity)] (all with normal or high enzymatic activity)

Figure 12 depicts a meta-analysis 1 of sensitivity and specificity of genotyping TPMT *2, *3A, *3B, *3C, *3D, *4, *5, *6, *7, *8, *10, *14, and *15, to diagnose TPMT activity. The figure is divided into three columns with the heading reading left to right: Study, Sensitivity† Specificity‡, and Sensitivity and Specificity (95 percent confidence interval). From left to right, the results are: Hindorf, 2006-- 20/23--91.7 (58.7, 98.8); and 39/40--97.5 (84.3, 99.6); Lindquist, 2006--7/11-- 63.6 (33.9, 85.7) and 48/49--98.0 (96.2, 99.8); Hindorf, 2010--20/23--87.0 (66.5, 95.7)and 204/206--99.0 (96.2, 99.4); Pooled--81.3 (59.9, 92.7) and 98.5 (96.1, 99.4).

Figure 13 Meta-analysis 2 of specificity of genotyping TPMT *2, *3A, *3B, *3C, *3D, *4, *5, *6, *7, *8, *10, *14, and *15, to diagnose TPMT activity

† [underlined: (Homozygous with low/absent enzymatic activity)] (all with low/absent enzymatic activity)

‡ [underlined: (Noncarriers (wild type) and/or heterozygotes with normal/intermediate/high enzymatic activity)] (all with normal, intermediate or high enzymatic activity)

Figure 13 depicts a meta-analysis 1 of sensitivity and specificity of genotyping TPMT *2, *3A, *3B, *3C, *3D, *4, *5, *6, *7, *8, *10, *14, and *15, to diagnose TPMT activity. The figure is divided into three columns with the heading reading left to right: Study, Sensitivity† Specificity‡, and Sensitivity and Specificity (95 percent confidence interval). From left to right, the results are: Hindorf, 2006--6/6--92.9 (42.3, 99.6) and 46/46--98.9 (85.1, 99.9); Lindqvist, 2006--1/1--75.0 (10.9, 98.7) and 59/59--99.2 (88.0, 99.9); Hindorf, 2010--0/0 and 229/229--99.8 (96.6, 100); Pooled--87.1 (44.3, 98.3) and 99.4 (7.2, 99.9).

Key points. A total of 16 studies, mostly of cross-sectional and prospective observational design, contributed to quantitative syntheses.1,46,49–53,56,59,70,93,157,158,161,162,167 Studies did not specifically examine diagnostic accuracy of genetic testing with the TPMT enzymatic activity test as the reference standard, so we designated the activity test to be the reference standard and genotyping to be the index test. Overall, homozygosity for variant allele(s) was quite low in the study samples. Different combinations of TPMT variant alleles were analyzed in various studies. Thirty-seven percent of the studies were rated as of poor quality.

Across all the combinations of alleles tested, an imprecise pooled sensitivity of the carrier genotype (i.e. homozygous plus heterozygous patients) to correctly identify all those patients with subnormal (intermediate, or low to absent) enzymatic activity, as determined by TPMT assays, was in the range of 70.70 to 82.10 percent (95 percent CI, lower bound range 37.90 to 54.00 percent; upper bound range 84.60 to 96.90 percent).

The pooled sensitivity of a homozygous TPMT genotype to correctly identify patients with low to absent enzymatic activity was based on two studies with two percent of 341 patients identified as homozygous for variant allele. The pooled sensitivity was 87.10 percent (95 percent CI 44.30 to 98.30 percent).

Meta-regression analysis did not identify any significant effect modifiers.

Compared with the reference standard of TPMT enzymatic activity, the specificity of TPMT genotyping to correctly identify patients with normal/high enzymatic activities, or normal/high and intermediate enzymatic activities, is very high (greater than 90 percent) across all combinations of alleles tested.

There is insufficient data to determine the optimum combination of TPMT alleles for testing. Most studies tested at least the TPMT *3A, *3B, and *3C variant alleles, irrespective of testing additional polymorphisms.

### Key Question 2 Does the measurement of TPMT enzymatic activity or determination of TPMT allelic polymorphisms change the management of patients with chronic autoimmune disease when compared with no determination of TPMT status?

The evidence to answer this question came from one randomized controlled trial of fair quality in 333 patients with inflammatory conditions, mostly inflammatory bowel disease (Figure 14 and Appendix C, Tables C7–9).1 Patients were randomized into either a group that had prior TPMT genotyping or one without pretesting. Where applicable, therapy was advised to be guided by genotyping results, however, all treatment decisions were at the discretion of treating physicians. Over a 4 month period, no significant differences between starting doses administered with or without prior knowledge of TPMT genotype were observed in both the noncarriers and heterozygous carrier patients. However, in the genotyped treatment arm, heterozygotes received significantly lower doses of TPMT when compared with noncarriers. Most patients in both groups were given starting doses lower than 2mg/kg/day including those with predisclosed noncarrier genotype. About seven percent of those in whom noncarrier genotype was predisclosed received AZA doses ≥2mg/kg/day as compared to 8.4 percent of those in whom noncarrier genotype was found out after the fact. Furthermore, there was no significant difference between the two groups in terms of mean AZA prescribed dose at the end of the study period. There is limited applicability of this evidence because there was just one homozygous carrier in the whole sample of mostly IBD patients.

Figure 14 Risk of bias of the randomized controlled trial answering KQ 2

Figure 14 depicts a bar chart, with bars going left to right, titled, risk of bias of the randomized controlled trial answering KQ2. The percentages range from 0 percent to 100 percent. They are colored to depict one of three different answers to each question. The answers could either be yes, no, or unclear. For the question, "True randomization?", the answer is yes 100 percent; "adequacy of allocation concealment?", unclear 100 percent; "blinding of investigators and participants?", no 100 percent; blinded assessment of outcomes?", yes 100 percent; "groups similar at baseline?", yes 100 percent; "outcomes described?", 100 percent yes; "intention to treat analysis?", yes 100 percent; "potential for conflict of interest?", no 100 percent; "high loss to follow-up or important differntial loss to follow-up between groups?", no 100 percent; "thiopurine adherence assessed?, yes 100 percent.

### Key Question 3a In chronic autoimmune disease patients prescribed thiopurine-based drugs (AZA or 6-MP), does the assessment of TPMT status to guide therapy, when compared with no pretreatment assessment, lead to reduction in rates of mortality, infection, hospitalization, withdrawal due to adverse events (WDAE), serious adverse events (SAE) and improvement in health-related quality of life?

The evidence to answer this question came from one randomized controlled trial of fair quality in 333 patients with inflammatory conditions, mostly inflammatory bowel disease (Figure 15 and Appendix C, Tables C 10–12).1 Patients were randomized into either a group that had prior TPMT genotyping or another without pretesting. Where applicable, therapy was advised to be guided by genotyping results; however, all treatment decisions were at the discretion of treating physicians. Over a 4 month period, no significant differences were seen in the outcomes of mortality [1/167 versus3/166; odds ratio 0.33 (95 percent CI, 0.03 to 3.18 percent)]; SAE [4/167 versus 8/166; odd ratio 0.48 (95 percent CI 0.14 to 1.64 percent)]; and WDAE (0/167 versus 0/166). Other outcomes were not reported including the important outcome of health-related quality of life.

Figure 15 Risk of bias of the randomized controlled trial answering KQ 3a

Figure 15 depicts a bar chart, with bars going left to right, titled, risk of bias of the randomized controlled trial answering KQ3a. The percentages range from 0 percent to 100 percent. They are colored to depict one of three different answers to each question. The answers could either be yes, no, or unclear. For the question, "True randomization?", the answer is yes 100 percent; "adequacy of allocation concealment?", unclear 100 percent; "blinding of investigators and participants?", no 100 percent; blinded assessment of outcomes?", yes 100 percent; "groups similar at baseline?", yes 100 percent; "outcomes described?", yes 100 percent; "intention to treat analysis?", yes 100 percent; "potential for conflict of interest?", no 100 percent; "high loss to follow-up or important differntial loss to follow-up between groups?", no 100 percent; "thiopurine adherence assessed?, yes 100 percent.

Strength of evidence answering key question 3a. The evidence was rated following published guidance39 as follows:

Table 17 Rating the strength of evidence-key question 3a

Outcome | N of studies | N of Subjects | Domains pertaining to strength of evidence | | | | OR (95% CI) | Strength of evidence
| | | Risk of Bias | Consistency | Directness | Precision
Mortality | 1^1^ | 333 | Medium | Unknown | Direct | Imprecise | 0.33 (0.03, 3.18) | Insufficient
Serious adverse events | 1^1^ | 333 | Medium | Unknown | Direct | Imprecise | 0.48 (0.14, 1.64) | Insufficient
Health-related quality of life | 0 | 0 | - | - | - | - | - | Insufficient

There is limited applicability of this evidence as there was just one homozygous carrier of TPMT variant allele in the entire sample of mostly IBD patients observed for just 4 months. Also, patients likelier to experience adverse events were excluded.

### Key Question 3b In chronic autoimmune disease patients prescribed thiopurine-based drugs (AZA or 6-MP), does the assessment of TPMT status to guide therapy, when compared with no pretreatment assessment, lead to reduction in rates of myelotoxicity, liver toxicity, and pancreatitis?

The evidence to answer this key question was available from one randomized controlled trial and one retrospective cohort study (Appendix C, Tables C13-15).1,169 No significantly reduced event rates were noted for intermediate outcomes in the pretested versus the nonpretested groups.

One trial of fair quality in 333 patients with inflammatory conditions, mostly inflammatory bowel disease, in which patients were randomized into either a group that had prior TPMT genotyping or another without pretesting (Figure 16).1 Where applicable, therapy was advised to be guided by genotyping results, however, all treatment decisions were at the discretion of treating physicians. Over a 4 month period, No significant differences were seen in the outcomes of neutropenia [2/167 versus 1/166; odd ratio 2.00 (95 percent CI 0.18 to 22.27 percent)]; and pancreatitis [1/167 versus 4/166; odd ratio 0.24 (95 percent CI 0.03 to 2.21 percent)]; while significantly higher odds were observed for hepatitis in the group that underwent prior TPMT genotyping [19/167 versus 8/166; odds ratio 2.54 (95 percent CI 1.08 to 5.97 percent)]. Other intermediate outcomes were not reported. There is limited applicability of this evidence as there was just one homozygous carrier in the whole sample of patients observed for just 4 months. Also, patients likelier to experience adverse events were excluded.

Figure 16 Risk of bias of the single randomized controlled trial answering KQ 3b

Figure 16 depicts a bar chart, with bars going left to right, titled, risk of bias of the single randomized controlled trial answering KQ3b. The percentages range from 0 percent to 100 percent. They are colored to depict one of three different answers to each question. The answers could either be yes, no, or unclear. For the question, "True randomization?", the answer is yes 100 percent; "adequacy of allocation concealment?", unclear 100 percent; "blinding of investigators and participants?", no 100 percent; blinded assessment of outcomes?", yes 100 percent; "groups similar at baseline?", yes 100 percent; "outcomes described?", yes 100 percent; "intention to treat analysis?", yes 100 percent; "potential for conflict of interest?", no 100 percent; "high loss to follow-up or important differntial loss to follow-up between groups?", no 100 percent; "thiopurine adherence assessed?, yes 100 percent.

Banerjee et al.’s was a retrospective cohort study in a pediatric population with IBD, treated with at least 4 months of stable dose treatment with azathioprine (AZA) or 6-mercaptopurine (6-MP).169 Ninety percent of patients received AZA. The study group was comprised of 64 patients who received initial AZA dosing based on TPMT enzymatic activity as measured by the high performance liquid chromatography (HPLC) method, with subsequent dose titrations based on 6-thioguanine nucleotide and 6-methylmercaptopurine levels. A historical control of 37 patients had been started on AZA 1.5 mg/kg/day and subsequent doses were adjusted based on clinical response and drug toxicity. Fourteen percent of patients had intermediate TPMT enzymatic activity and none had low/zero activity. On average, the study group received 1.7 mg/kg/day of AZA treatment and the control 1.2 mg/kg/day. A statistically significant difference was not observed for the outcome of leukopenia (study versus control group; 4.7 percent versus 0 percent) and hepatotoxicity (study versus control group; 9.4 percent versus 16.2 percent). The overall risk of bias assessment rated this evidence as poor, based on several limitation (Figure 17).

Figure 17 Risk of bias of the single retrospective cohort study answering KQ 3b

Figure 17 depicts a bar chart, with bars going left to right, titled, risk of bias of the single retrospective cohort study answering KQ3b. The percentages range from 0 percent to 100 percent. They are colored to depict one of three different answers to each question. The answers could either be yes, no, or unclear. For the question, "Investigators and particpats blinded to testing" the answer is unclear 100 percent; "Blinded assessment of outcomes?", unclear 100 percent; "Groups comparable at baseline?, yes 100 percent; outcomes adequately described?", yes 100 percent; "Intention to treat anaylsis?", yes 100 percent; "potential for conflict of interest?", no 100 percent; "High loss to follow-up or differential loss to follow-up between groups?", no 100 percent; "Adequate sample size?", yes 100 percent; "Selection bias minimized?", unclear 100 percent; "Methods to control for concounding?", unclear 100 percent; "Appropriateness of the TPMT test?", yes 100 percent.

Strength of evidence answering key question 3b. The evidence was rated following published guidance39 as follows:

Table 18 Rating the strength of evidence-key question 3b

Outcome | N of studies | N of Subjects | Domains pertaining to strength of evidence | | | | OR (95% CI) | Strength of evidence
| | | Risk of Bias | Consistency | Directness | Precision
Myelotoxicity | 0 | 0 | - | - | - | - | - | Insufficient

### Key Question 3c In the absence or inconclusiveness of evidence answering key question 3a and/or 3b above, is there an association between TPMT status (as determined by TPMT enzymatic activity and/or TPMT allelic determination) and/or the following amongst chronic autoimmune disease patients treated with thiopurines: i) the clinical outcomes of mortality, infections, hospitalization, withdrawal due to adverse events (WDAE), serious adverse events (SAE) and health-related quality of life? ii) surrogate outcomes of myelotoxicity, liver toxicity, and pancreatitis?

(see Results Update)

#### TPMT Enzymatic Activity Determination

Sixteen of the eligible studies reported relevant data (Table 19). No evidence was available for the outcomes of mortality, hospitalization, SAE, and HQOL. The sparse data available for the outcomes of infection, neutropenia and thrombocytopenia, did not permit a meaningful analysis.

Table 19 Summary characteristics of TPMT enzymatic activity and thiopurine toxicity association studies

Characteristic | | Number of studies | References
Study Design | Case Control | 1 | 197
Study Design | Chart Review | 1 | 157
Study Design | Cohort | 1 | 195
Study Design | Cross-Sectional | 10 | 50,51,53,70,79,93,161,192,193,196
Study Design | NonRandomized Intervention Study | 1 | 91
Study Design | Prospective Observational | 1 | 72
Study Design | Randomized Controlled Trial | 1 | 52
Chronic Autoimmune Disease | AntiNeutrophil Cytoplasmic Antibody Associated Vasculitis | 1 | 157
Chronic Autoimmune Disease | Autoimmune Dermatologic Conditions | 1 | 93
Chronic Autoimmune Disease | Autoimmune Disorders | 2 | 195,197
Chronic Autoimmune Disease | Autoimmune Hepatitis | 1 | 79
Chronic Autoimmune Disease | Inflammatory Bowel Disease | 8 | 50–52,70,72,161,192,196
Chronic Autoimmune Disease | Pemphigus Vulgaris | 1 | 193
Chronic Autoimmune Disease | Rheumatoid Arthritis | 1 | 91
Chronic Autoimmune Disease | Systemic Lupus Erythematosus | 1 | 215
Chronic Autoimmune Disease | Not Reported
Thiopurine Treatment | 6-MP, AZA | 1 | 196
Thiopurine Treatment | AZA | 14 | 50,50,52,53,70,72,91,93,157,161,192,193,195,197
Thiopurine Treatment | Mixed Thiopurines | 1 | 51
Assay Type | High Performance Liquid Chromatography | 4 | 51,53,157,193
Assay Type | Mass Spectrometry | 1 | 70
Assay Type | Radioassay | 9 | 50,52,72,79,91,93,161,195,197
Assay Type | Not Reported | 2 | 192,196
Outcomes Assessed | Anemia | 2 | 193,197
Outcomes Assessed | Any Infection | 1 | 91
Outcomes Assessed | Hepatitis | 9 | 50–52,70,72,91,93,193,196
Outcomes Assessed | Leukopenia | 8 | 53,70,93,157,193,195–197
Outcomes Assessed | Myelotoxicity | 7 | 50–52,72,91,195,197
Outcomes Assessed | Neutropenia | 1 | 161
Outcomes Assessed | Pancreatitis | 6 | 50–52,70,72,193
Outcomes Assessed | Thrombocytopenia | 1 | 197
Outcomes Assessed | Withdrawal due to Adverse Events | 4 | 52,79,192,193
Age Group | Adults | 8 | 50,52,72,79,91,93,195,216
Age Group | Mixed | 3 | 51,53,196
Age Group | Not Reported | 5 | 70,157,161,192,193
Setting | Outpatient Specialty Clinics | 5 | 51,70,91,161,193
Setting | Not Reported | 11 | 50,52,53,72,79,93,157,192,195–197
Region | Asia | 1 | 53
Region | Europe | 9 | 50–52,70,72,79,91,192,195
Region | Europe and North America | 1 | 217
Region | Middle East and North Africa | 1 | 193
Region | North America | 2 | 93,196
Region | Not Reported | 2 | 157,161
Risk of Bias | Fair | 12 | 50–53,70,72,79,91,157,161,193,195
Risk of Bias | Poor | 4 | 93,192,196,197

Abbreviations: 6-MP = 6-mercaptopurine; AZA = azathioprine; TPMT = thiopurine methyltransferase

Characteristics of included studies and quality are summarized in Table 19. Approximately 50 percent of studies were in populations with IBD. In 12 studies reporting gender distribution, female representation was on average 50 percent.50–52,70,72,79,91,93,161,193,196,197 Racial distribution was very poorly reported. In 80 percent of included studies, thiopurine treatment was restricted to AZA, and when reported dosages were generally in the range 1.5–2.5mg/kg/day.50,52,53,70,72,91,93,157,161,192,193,195,197 The adverse event observation period on thiopurine treatment ranged between six and 48 months (average 20 months) while four studies did not report this information.53,93,193,195 Over sixty percent of studies were cross-sectional in design, and most studies were rated as fair quality. Most importantly, biased enzymatic activity determination based on prior knowledge of outcomes or outcomes assessment based on prior knowledge of enzymatic activity results could not be clearly ruled out in any one of the studies addressing this question. No study was rated as good quality, 25 percent were rated as poor and the rest were judged as fair.

Figure 18 depicts the distribution of studies by individual quality scoring items. Detailed results of all 16 studies are available in Appendix C.

Figure 18 Risk of bias of TPMT enzymatic activity, and thiopurine toxicity association studies

Figure 18 depicts a bar chart, with bars going left to right, titled, risk of bias of TPMT enzymatic activity, and thiopurine toxicity association studies. The percentages range from 0 percent to 100 percent. They are colored to depict one of three different answers to each question or statement. The answers could either be yes, no, or unclear. For the statement, "clearly there is no biased assessment of outcomes and/or phenotyping results based on a prior knowledge of each other.", the answer is unclear 100 percent; "Comparability of groups at baseline?", no six percent, unclear 94 percent; Outcomes adequately described?" yes, 69 percent, no 25 percent, unclear 6 percent; "Intention to treat analysis?", yes 50 percent, no 31 percent, and unclear 19 percent; "Potential for financial conflict of interest?", yes six percent, no 94 percent; "High loss to follow-up or important differential loss to follow-up between groups?", yes 19 percent, no 69 percent, unclear 13 percent; "Adequacy of sample size?", unclear 100 percent; "Unbiased selection of participants?", yes six percent, no 25 percent, unclear 69 percent; "Methods to control for confounding?", yes six percent, no 88 percent, unclear 6 percent; "Appropriatesness TPMT activity testing method?", yes 81 percent, unclear 19 percent.

Withdrawal due to adverse events. Insufficient evidence addressed withdrawal due to adverse events in patients with low/absent TPMT activity. Compared with normal TPMT enzymatic activity, intermediate activity was not significantly associated with withdrawals (OR 1.75, 95 percent CI 0.75 to 4.11) ( Figure 19).52,79,192,193

Figure 19 Odds ratio of withdrawal due to adverse events during thiopurine treatment of chronic autoimmune disease; intermediate versus normal enzymatic activities

Figure 19 depicts a chart titled, "Odds ratio of withdrawal due to adverse events during thiopurine treament of chronic autoimmune disease; intermediate versus normal enzymatic activities. The withdrawal events are listed on the left of the ratio line, and the total number is listed on the other. There are four columns; column one is study name, column two is intermediate, column three is normal, and colum four shows a line graph with dots on number lines showing whether the response shows favors intermediate or favors normal.

Myelotoxicity. Myelotoxicity was defined variably, in some studies including at least two myeloid cell lines (e.g. leukopenia and thrombocytopenia)50–52,91,195 or was not clearly defined.72,197 A nonsignificant odds ratio was noted for the outcome of myelotoxicity when intermediate enzymatic activity was compared with normal TPMT activity,50,51,72,91,195 but significant odds favoring higher activities were found when low enzymatic activity was compared with normal (OR 13.6, 95 percent CI 3.52 to 52.80) and intermediate (OR 10.2, 95 percent CI 2.23 to 46.60) activities (Figure 20).50,50,197 The overall event rate of myelotoxicity was 5 percent among 996 patients.

Figure 20 Odds ratios of myelotoxicity during thiopurine treatment of chronic autoimmune disease; intermediate/normal, low/intermediate and low/normal comparisons

Figure 20 depicts a chart titled, "Odds ratios of myelotoxicity during thiopurine treatment of chronic autoimmune disease; intermediate/normal, low/intermediate and low/normal comparisons." In the chart intermediate vs. normal, there are number on either side of a slash line that are events/total number. There are four columns. Study name, Intermediate, Normal, and a number chart showing odds ration and 95 percent confidence interval. Conclusions on this chart are 1.96 (0.90, 4.25). The second chart in named low versus intermediate. the conclusions on this chart are 10.2 (2.23, 46.6). The final chart, low versus normal, has conclusions of 13.6 odds ratio with a 95 percent confidence interval of (3.52, 52.8).

Leukopenia. Leukopenia was experienced by 12 percent of participants, and a significant dose response relationship was observed. When low and intermediate activities were compared with normal activities and with each other, a significantly higher number of patients with lower enzymatic activities experienced leukopenia. In a total of 538 patients in seven studies, significant odds ratios of intermediate versus normal were 2.96 (95 percent CI 1.18 to 7.42);53,70,93,157,193,195,196 low versus intermediate of 29.2 (95 percent CI 4.55 to 188) in three studies with 247 participants;70,195,197 and a low versus normal activity odds ratio of 80.00 (95 percent CI 11.5 to 559) in three studies with 247 participants (Figure 21).70,195,197

Figure 21 Odds ratios of leukopenia during thiopurine treatment of chronic autoimmune disease; intermediate/normal, low/intermediate and low/normal comparisons

Figure 21 depicts a chart titled "Odds ratios of leukopenia during thiopurine treatment of chronic autoimmune disease; intermedia/normal, low/intermediate and low/normal comparisons. The conclusions of the intermediate versus normal are 2.96 with a confidence interval of (1.18, 7.42). The conclusions of low versus intermediate are 29.2 odds ratio with a 95 percent confidence interval of (4.55, 188). The conclusions of low versus normal are odds ratio of 80 with a confidence interval of (11.5, 559).

Anemia. Two studies in 246 patients found no significant difference between patients with intermediate enzymatic activity and normal activity, in development of anemia during thiopurine treatment (Figure 22).157,193 Insufficient evidence was available to compare low enzymatic activity with higher activity.

Figure 22 Odds ratio of anemia during thiopurine treatment of chronic autoimmune disease; intermediate versus normal TPMT enzymatic activities

Figure 22 depicts a chart titled "Odds ratio of anemia during thippurine treatment of chrnoic autoimmune disease; intermediate versus normal TPMT enzymatic activities." The conclusions shown are odds ratio of 2.04 and a 95 percent confidence interval of (0.50, 8.27).

Hepatitis or elevated hepatic transaminases. No significant association between enzymatic activities and odds of developing hepatoxicity was evident in seven studies.(Figure 23).

Figure 23 Odds ratios of hepatitis or elevated hepatic transaminases during thiopurine treatment of chronic autoimmune disease: intermediate/normal, low/intermediate and low/normal comparisons

Figure 23 depicts a three charts titled, "Odds ratios of hepatitis or elevated hepatic transaminases during normal thiopurine treatment of chronicautoimmune disease: Intermediate/normal, low/intermediate, and low normal comparisons. The conclusions in the Intermediate versus normal chart are an odds ratio of 1.74 (with a confidence interval of (0,80, 3.77). The conclusions on the chart titled low versus intermediate are: an odds ratio of 1.36 and a 95 percent confidence interval of (0.13, 13.9). The conclusions on the chart low versus normal are an odds ratio of 2.34 with a confidence interval of (0.26, 20.7).

Pancreatitis. Insufficient evidence was available to compare low enzymatic activity with normal activity. Odds of pancreatitis were nonsignificant when intermediate activity was compared with normal activity (OR 1.79, 95 percent CI 0.65 to 4.99) and low with intermediate activity (OR 2.01, 95 percent CI 0.19 to 21.60) (Figure 24).

Figure 24 Odds ratios of pancreatitis during thiopurine treatment of chronic autoimmune disease: intermediate/normal, and low/intermediate comparisons

Figure 24 depicts two charts titled, "Odds ratios of pancreatitis during thiopurine treatment of chronic autoimmune disease: intermediate/normal, and low/intermediate comparisons. The conclusions of the odds ratio of the first study, intermediate versus normal are 1.79 with a confidence interval of (0.65, 4.99). The conclusions of the next study, low versus intermediate are an odds ratio of 2.01 and a 95 percent confidence interval of (0.19, 21.6).

Key points. Fifteen studies contributed to quantitative syntheses regarding association of thiopurine treatment toxicity with TPMT enzymatic activity.50–53,70,72,79,91,93,157,192,193,195–197

A dose response relationship was demonstrated for the association of subnormal TPMT enzymatic activities and the outcome of leukopenia. The greatest odds of the outcome were noted when the enzymatic activity was low followed by when it was intermediate in comparison with normal enzymatic activity.

Greater odds for the outcome of myelotoxicity were also noted with low activity when compared with intermediate and normal TPMT enzymatic activities.

No evidence was available for the outcomes of mortality, hospitalization, SAE, and HQOL. Sparse data were available for the outcome of infection, neutropenia and thrombocytopenia, not permitting a meaningful analysis.

#### TPMT Allelic Determination

Genotyping was reported in thirty-four of the eligible studies (Table 8). Data reported for individual allelic variants were too sparse to permit a meaningful allele specific evidence synthesis. Insufficient evidence of association was available for the outcomes of mortality, hospitalization, serious adverse events (SAE), health related quality of life (HQOL) and neutropenia. Five studies reported outcomes data associated with compound heterozygosity, so these participants were evaluated as homozygous carriers.57,159,160,172,176

Characteristics of included studies and risk of bias are summarized in Table 20. The majority (68 percent) of studies were in IBD patients. Overall, females were approximately equally represented, although this data could not be ascertained in nine studies53,57,61,81,157,170,176,179,182 and in five studies females were overrepresented.89,99,171,174,190 Racial distribution was very poorly reported.

Table 20 Summary characteristics of TPMT allelic determination and thiopurine toxicity association studies

Characteristic | | Number of studies | Studies
Study Design
| Case Control | 4 | 81,86,181,182
| Chart Review | 1 | 157
| Cross-Sectional | 18 | 48,50,51,53,57,59,70,93,99,170–176,190,191
| NonRandomized Intervention Study | 2 | 46,54
| Prospective Observational | 7 | 1,47,61,89,177,180,186
| Randomized Controlled Trial | 1 | 52
| Unclear whether prospective or retrospective design | 1 | 179
Chronic Autoimmune Disease
| AntiNeutrophil Cytoplasmic Antibody Associated Vasculitis | 1 | 157
| Autoimmune Dermatologic Conditions | 2 | 93,170
| Autoimmune Hepatitis | 1 | 171
| Inflammatory Bowel Disease | 23 | 1,46–48,50–52,54,59,61,70,81,86,172,173,175–177,180–182,186,191
| Rheumatoid Arthritis | 2 | 57,179
| Rheumatic Diseases | 2 | 89,190
| Systemic Lupus Erythematosus | 4 | 53,99,174,179
Thiopurine Treatment
| 6-MP | 1 | 54
| 6-MP, AZA | 5 | 47,176,177,181,186
| AZA | 25 | 1,46,48,50,52,53,59,61,70,86,89,93,99,157,170–175,179,180,182,190,191
| Mixed Thiopurines | 2 | 51,81
| Not Reported | 1 | 57
Allelic Variants Tested
| TPMT*1, *2, *3A, *3B, *3C | 4 | 173,179–181
| TPMT*1, *2, *3A, *3C | 1 | 81
| TPMT*2, *3A | 1 | 89
| TPMT*2, *3A, *3B, *3C | 17 | 1,48,51–54,59,70,99,157,170–172,176,186,190,191
| TPMT*2, *3A, *3B, *3C, *3D | 1 | 182
| TPMT*2, *3A, *3B, *3C, *3D, *4, *5, *6, *7, *8, *10, *14, *15 | 1 | 50
| TPMT*2, *3A, *3B, *3C, *3D, *6 | 1 | 174
| TPMT*2, *3A, *3B, *3C, *7, *8 | 1 | 57
| TPMT*2, *3A, *3C | 1 | 86
| TPMT*3A, *3B, *3C | 4 | 46,47,175,177
| Not Reported | 2 | 61,93
Genotyping Method
| High Performance Liquid Chromatography | 1 | 181
| Polymerase Chain Reaction | 28 | 1,47,48,51–54,57,59,61,70,81,86,89,157,170–177,179,180,186,190,191
| Pyrosequencing | 1 | 50
| Not Reported | 4 | 46,93,99,182
Outcomes Reported
| Mortality | 1 | 1
| SAE | 1 | 1
| Anemia | 2 | 157,170
| Any Infection | 3 | 59,170,190
| Hepatitis | 20 | 1,46–48,50–52,54,59,61,70,81,86,89,93,99,172–175
| Leukopenia | 25 | 46–48,53,54,61,70,81,89,93,99,157,170,172–177,179–181,186,190,191
| Myelotoxicity | 6 | 50–52,59,171,180
| Neutropenia | 3 | Insufficient evidence with sparse events1,86,170
| Pancreatitis | 14 | 1,46–48,50–52,54,59,70,81,86,172,182
| Thrombocytopenia | 4 | 48,61,157,190
| Withdrawal due to Adverse Events | 5 | 1,46,57,170,190
Age Group
| Adults | 15 | 1,46,47,50,52,54,81,93,171,173,175,180,186,190,191
| Children | 3 | 99,172,177
| Mixed | 5 | 48,51,53,86,181
| Not Reported | 11 | 57,59,61,70,89,157,170,174,176,179,182
Setting
| Inpatient | 1 | 170
| Outpatient Specialty Clinics | 15 | 1,48,51,54,57,59,70,81,86,89,173,175–177,181
| Not Reported | 18 | 46,47,50,52,53,61,93,99,157,171,172,174,179,180,182,186,190,191
Region
| Asia | 6 | 53,171,174,176,179,181
| Europe | 20 | 1,46–48,50–52,54,57,59,70,86,89,170,172,173,175,180,190,191
| North America | 2 | 93,177
| Oceania | 1 | 81
| Not Reported | 5 | 61,99,157,182,186
Risk of Bias
| Good | 1 | 1
| Fair | 29 | 46–48,50–54,57,59,61,70,81,86,89,157,170–177,179–181,190,191
| Poor | 4 | 93,99,182,186

Abbreviations: 6-MP = 6-mercaptopurine; AZA = azathioprine; TPMT = thiopurine methyltransferase

In 17 studies, thiopurine treatment was restricted to AZA mostly in the doses varying from 1–2 mg/kg/day of AZA1,46,48,52,59,70,86,89,93,170–175,179,190 while eight studies did not report AZA dose.50,53,61,99,157,180,182,191 One study employed 6-MP in a dose of 50mg/kg/day,54 while the rest used mixed thiopurines. Adverse event observation periods on thiopurine treatment varied but when reported were mostly greater than 2 months in duration. Nine studies did not report the period of on-thiopurine-treatment observation for adverse events.53,57,61,81,93,99,171,177,182 Most studies were cross-sectional in design, in which patients’ past thiopurine treatment and related adverse events were correlated with study genotyping results. These were generally rated as fair risk of bias. Most importantly, biased genotyping based on prior knowledge of outcomes or outcomes assessment based on prior knowledge of genotyping results could be ruled out only in five studies.1,46,48,89,177

Figure 25 depicts the distribution of studies by individual quality scoring items. Except for Ansari et al.’s study for which data on the homozygous carrier state was not reported, we tested studies for Hardy-Weinberg equilibrium (HWE) but did not consider it an item for sensitivity analyses.46 Six studies were not found in equilibrium,47,50,86,172,173,190. Detailed results of all 34 studies are available in Appendix C. Below we first present the pooled results from studies that tested for the most common of TPMT variant alleles (TPMT*2, *3A, *3B, *3C), whether or not testing additional polymorphisms. Subsequently we report results from subgroups of studies testing specific sets of variant alleles.

Figure 25 Risk of bias of TPMT allelic determination and thiopurine toxicity association studies

Figure 25 is depicts a bar chart with results running left to right. The results of yes, no, and unclear are listed as percentages. The title of the chart is Risk of bias of TPMT alllelic determination and thiopurine toxicity association studies.The percentages range from 0 percent to 100 percent. They are colored to depict one of three different answers to each question. The answers could either be yes, no, or unclear. For the question, Genotype groups comparable?, thr results are 3 percent yes, 97 percent unclear. The question, Participants enrolled without prior knowledge of genotype resulted in 79 percent yes, and 21 percent unclear. For the question, Outcomes and genotyping blinded to each other, 15 percent yes and 85 percent unclear. For the question, Genotyping method described adequately, 62 percent said yes, 32 percent said no, and 6 percent were unclear. For the quesion Ambigous results of genotyping reported, the results are 6 percent yes, 79 percent no, and 15 percent unclear. for the question, Deviation from Hardy-Weinberg equilibrium tested, the results were 6 percent yes, 91 percent no, and 3 percent unclear. For the question, Gene-gene interaction assessed, the results were 3 percent yes, 85 percent no, and 12 percent unclear. For the question Thiopurine adhearance assessed, the results were 6 percent yes, 79 percent no, and 15 percent unclear. for the question, differenct sources of DNA-potential measurement bias, the results were 76 percentno, and 24 percent unclear. for the question, Lost-to-followup reporting? the results were 44 percent yes, 50 percent no, and 6 percent unclear. for the question, possibility of survival bias, the results were 53 percent no, and 47 percent unclear. For the question, Potential for finalcial conflict of interest, the results were 6 percent yes, 59 percent no, and 35 percent unclear.

Infection. Three studies of cross-sectional study design reported infection in association with thiopurine treatment, including 155 patients with chronic autoimmune diseases.59,170,190 No significant association was noted between heterozygous and noncarrier carrier states when most common variant alleles (TPMT*2, *3A, *3B, *3C) were tested (OR 1.37, 95 percent CI 0.22 to 8.64). Insufficient data were available to evaluate homozygous carrier state (Figure 26).

Figure 26 Meta-analysis of odds ratios of infections during thiopurine treatment of chronic autoimmune disease, heterozygotes versus noncarriers

Figure 26 depicts a chart of Meta analysis of odds ratios of infections during thiopurine treatment of chronic autoimmune disease, heterozygotes versus noncarriers. The results are Odds ratio of 1.37 with a confidence interval of (0,22, 8.64) favoring noncarriers.

Withdrawal due to adverse events. Four studies with an analyzable sample size of 317 reported this outcome. There were no withdrawals due to adverse events in 166 patients on azathioprine for 4 months administered in doses not guided by prior TPMT status determination.1 The remaining studies of cross-sectional design, that tested for the most common variant alleles (TPMT*2, *3A, *3B, *3C) in 151 participants demonstrated no significant difference between heterozygous carriers and noncarriers in withdrawal due to adverse events on thiopurine treatment (OR 3.46, 95 percent CI 0.50 to 23.80) (Figure 27).57,170,190 Insufficient data were available to investigate the homozygous carrier state.

Figure 27 Odds ratio of withdrawal due to adverse events during thiopurine treatment of chronic autoimmune disease, heterozygotes versus noncarriers

Figure 27 depicts a chart of Odds ratio of withdrawal due to adverse events during thiopurine treatment of chronic autoimmune disease, heterozygotes versus noncarriers. The results are odds ratio of 3.46 with a 95 percent confidence interval of (0.50, 23.8) favoring noncarriers.

Myelotoxicity. Myelotoxicity was reflected in at least two cell lines (e.g. leukopenia and thrombocytopenia). The pooled estimate from four studies in 193 participants testing for the most common allelic variants (TPMT*2, *3A, *3B, *3C) demonstrated no significant difference between heterozygous carriers and noncarriers (OR 0.77, 95 percent CI 0.22 to 2.65).50,51,180,218 When homozygous carriers were compared with noncarriers, the nonsignificant odds ratio was 2.20 (95 percent 0.15 to 32.80).50,171 (Figure 28 and Figure 29). Data were insufficient to derive a pooled estimate for the difference in rates of myelotoxicity between the two carrier states.50

Figure 28 Odds ratio of myelotoxicity during thiopurine treatment of chronic autoimmune disease, heterozygotes versus noncarriers

Figure 28 depicts a chart of Odds ratio of myelotoxicity during thiopurine treatment of chronic autoimmune disease, heterozygotes versus noncarriers. The results are odds ratio of 0.77 with a confidence interval of 95 percent (0.22, 2.65) favoring noncarriers.

Figure 29 Odds ratio of myelotoxicity during thiopurine treatment of chronic autoimmune disease, homozygotes versus noncarriers

Figure 29 depicts a chart of Odds ratio of myleotoxicity during thiopurine treatment of chronic autoimmune disease, homozygotes versus noncarriers. The results are odds ratio of 2.20 with a confidence interval of 95 percent (0.15, 32.8) favoring noncarriers.

Leukopenia. Sixteen studies including a total of 1483 analyzable patients of whom 281 (19 percent) experienced leukopenia tested the four common variant alleles with or without additional variants.48,53,54,70,157,170,172–174,176,179–181,186,190,191 Odds of leukopenia were significantly higher when genotypes were heterozygous for TPMT mutations compared with noncarriers or wild type, and individual study results were quite consistent across studies (OR 4.62, 95 percent CI 2.34 to 9.16) (Figure 30). Meta-regression indicated significant differences in odds ratios with the method of genotyping (PCR versus HPLC). The study by Jae Hak et al., 2008 was the only study that used HPLC method for genotyping. A dose response relationship was indicated when homozygous carriers were compared with noncarriers (OR 18.60, 95 percent CI 4.12 to 83.60) (Figure 31).54,172,173,176,190 However, no significant differences in likelihood of leukopenia between the two carrier states were observed from pooling four small studies (Figure 32).54,172,173,176

Figure 30 Odds ratio of leukopenia during thiopurine treatment of chronic autoimmune disease, heterozygotes versus noncarriers

Figure 30 depicts a chart of Odds ratio of leukopenia during thiopurine treatment of chronic autoimmune disease, heterozygotes versus noncarriers. The results were an odds ratio of 10.0 with a confidence interval of 95 percent (2.34, 9.16) favoring noncarriers.

Figure 31 Odds ratio of leukopenia during thiopurine treatment of chronic autoimmune disease, homozygotes versus noncarriers

Figure 31 depicts a chart of Odds ratio of leukopenia during thiopurine treatment of chronic autoimmune disease, homozygotes versus noncarriers. The results are an odds ratio of 18.6 with a confidence interval of 95 percent (4.12, 83.6) favoring noncarriers.

Figure 32 Odds ratio of leukopenia during thiopurine treatment of chronic autoimmune disease, homozygotes versus heterozygotes

Figure 32 depicts a chart of Odds ratio of leukopenia during thiopurine treatment of chronic autoimmune disease, homozygotes versus heterozygotes. The results are an odds ratio of 1.66 with a confidence interval of 95 percent (0.22, 12.7) favoring heterozygotes.

Anemia. Two studies in 140 patients did not demonstrate a significant difference in incidence of anemia when patients heterozygous for the common TPMT allelic variants were compared with noncarrier patients (OR 1.44, 95 percent CI 0.36 to 5.82) (Figure 33). There were no data pertaining to TPMT homozygosity for this outcome.

Figure 33 Odds ratio of anemia during thiopurine treatment of chronic autoimmune disease, heterozygotes versus noncarriers

Figure 33 depicts a chart of Odds ratio of anemia during thiopurine treatment of chronic autoimmune disease, heterozygotes versus noncarriers. The results were an odds ratio of 1.44 with a 95 percent confidence interval of (0.36, 5.82) favoring noncarriers.

Thrombocytopenia. Based on a total of 256 patients in three studies, the pooled odds ratio for thrombocytopenia was 3.43 (95 percent CI, 0.52 to 22.60) when heterozygous genotypes were compared with noncarriers or wild type (Figure 34). Insufficient data were available to investigate the homozygous carrier state.

Figure 34 Odds ratio of thrombocytopenia during thiopurine treatment of chronic autoimmune disease, heterozygotes versus noncarriers

Figure 34 depicts a chart of an odds ratio of thrombocytopenia during treatment of chronic autoimmune disease, heterozygotes versus noncarriers. The results were an odds ratio of 3.43 and a 95 percent confidence interval of (0.52, 22.6) favoring noncarriers.

Hepatitis or elevated hepatic transaminases. Based on a total of 984 patients in ten studies, comparing heterozygous carriers with noncarriers, the pooled odds ratio for hepatitis or elevated hepatic transaminases was 1.35 (95 percent CI 0.59 to 3.11) (Figure 35).1,48,50–52,54,59,70,173,174 Meta-regression suggested a significant relationship between the genotyping method and the outcome (p<0.05). The study by Hindorf et al., which used a pyrosequencing method as opposed to the PCR used in the other studies, showed a nonsignificant point estimate in favor of heterozygosity because of zero events in the heterozygous group.50 When homozygous participants were compared with noncarriers, similar nonsignificant odds were noted ( Figure 36). Data were insufficient to compare the two carrier states.

Figure 35 Odds ratio of hepatotoxicity during thiopurine treatment of chronic autoimmune disease, heterozygotes versus noncarriers

Figure 35 depicts a chart of an odds ratio of hepatoxicity versus noncarriers. The results were an odds ratio of 1.35 with a 95 percent confidence interval of (0.59, 3.11) favoring noncarriers.

Figure 36 Odds ratio of hepatotoxicity during thiopurine treatment of chronic autoimmune disease, homozygotes versus noncarriers

Figure 36 depicts a chart of an odds ratio of hepatotoxicity during thiopurine treatment of chronic autoimmune disease, homozygotes versus noncarriers. The results are an odds ratio of 3.85 and a 95 percent confidence interval of (0.90, 16.5) favoring noncarriers.

Pancreatitis. When heterozygous carriers were compared with noncarriers, no significant difference in incidence of patients with pancreatitis was noted in ten studies of a total of 807 participants (OR 1.20, 95 percent CI 0.49 to 2.97) (Figure 37).1,48,50–52,54,59,70,172,182 However, meta-regression indicated a significant relationship with the overall risk of bias score with poor quality studies tended to report lower rates of pancreatitis in heterozygous participants compared with noncarriers.182 With fewer studies, no significant difference was noted in pancreatitis events when homozygous carriers were compared with noncarriers (Figure 38). Data were insufficient to compare the two carrier states of homozygosity and heterozygosity.

Figure 37 Odds ratio of pancreatitis during thiopurine treatment of chronic autoimmune disease, heterozygotes versus noncarriers

Figure 37 depicts a chart of an odds ratio of pancreatitis during thiopurine treatment of chronic autoimmune disease, heterozygotes versus noncarriers. The results are an odds ratio of 1.20 with a 95 percent confidence interval of (0.49, 2.97) favoring noncarriers.

Figure 38 Odds ratio of pancreatitis during thiopurine treatment of chronic autoimmune disease, homozygotes versus noncarriers

Figure 38 depicts a chart of an odds ration of pancreatitis during thiopurine treatment of chronic autoimmune disease, homozygotes versus noncarriers. The results are an odds ratio of 1.80 with a 95 percent confidence interval of (0.49, 6.69) favoring noncarriers.

Subgroup meta-analyses by specific sets of alleles tested. We also analyzed subgroups of studies testing specific sets of variant alleles (Table 21). Concordant with the main meta-analysis above in which studies that tested for TPMT*2, *3A, *3B, *3C with or without additional variants were pooled, studies that exclusively tested for TPMT *2, *3A, *3B, * 3C also demonstrated a pooled odds of leukopenia significantly greater with either carrier states in comparison with noncarriers. For other outcomes, comparatively fewer studies contributed subgroup specific evidence, with odds ratios failing to reach statistical significance.

Table 21 Pooled odds ratios of outcomes on thiopurine treatment between TPMT variant allele carriers and noncarriers, as well as between the two carrier states (allele specific subgroups)

TPMT alleles tested | Outcome | Homozygous carriers vs. noncarriers | | Heterozygous carriers vs. noncarriers | | Homozygous carriers vs. heterozygous
| | N of studies meta-analyzed | Odds Ratio (95% CI) | N of studies meta-analyzed | Odds Ratio (95% CI) | N of studies meta- analyzed | Odds Ratio (95% CI)
TPMT *2, *3A, *3B, * 3C
| Infection | X | | 3^59,170,190^ | 1.37 (0.22 to 8.64) | X
| WDAE | X | | 3^1,170,190^ | 1.06 (0.12 to 9.06) | X
| Myelotoxicity (11% of patients with events) | X | | 2^51,59^ | 0.40 (0.05 to 3.33) | X
| Leukopenia (13% of patients with events) | 4^54,172,176,190^ | [underlined: 12.50 (2.29 to 68.00)] Favors noncarrier | 12^48,53,54,70,99,157,170, 172,176,186,190,191^ | [underlined: 5. 60 (2.35 to 13.30)] Favors noncarriers | 3^54,172,176^ | 0.68 (0.08 to 5.70)
| Anemia | X | | 2^157,170^ | 1.44 (0.36 to 5.82) | X
| Thrombocytopenia | X | | 3^48,157,190^ | 3.43 (0.52 to 22.60) | X
| Hepatitis or raised hepatic transaminases | 2^1,54^ | 4.98 (0.44 to 56.30) | 8^1,48,51,52,54,59,70,99^ | 1.11 (0.39 to 3.10) | X
| Pancreatitis | 3^1,54,172^ | 3.27 (0.49 to 21.60) | 8^48,51,52,54,59,70,172^ | 2.22(0.78 to 6.32) | X
TPMT *3A, *3B, *3C
| Leukopenia | X | | 2^46,47,177^ | 5.13 (0.82 to 32.00) I^2^ > 50% and p- value for test of heterogeneity <0.10 | X
| Hepatitis or raised hepatic transaminases | | | 2^46,47^ | 0.98 (0.18 to 5.33) | X
| Pancreatitis | X | | 2^46,47^ | 0.48 (0.06, 3.60) | X
TPMT*1, *2, *3A, *3B, * 3C
| Leukopenia | X | | 4^173,179–181^ | [underlined: 5.23 (1.99 to 13.70)] | X

Notes: underlined odds ratios reached statistical significance.

Abbreviations: TPMT = thiopurine methytransferase; vs. = versus; X =absent or insufficient evidence

Key points. Thirty studies contributed to quantitative syntheses.1,46–48,50–54,57,59,70,99,157,170–177,179–182,186,190,191,219

A dose response relationship was suggested between TPMT genotypic status and leukopenia. In studies testing TPMT *2, *3A, *3B, * 3C plus/minus additional variants, homozygosity for the variant alleles yielded the highest odds ratio for leukopenia when compared with noncarrier status. Lower, but still significantly increased odds were seen for heterozygous patients versus noncarriers. However, direct comparison between the two carrier states did not yield statistically significant results.

For all other outcomes of mortality, hospitalization, serious adverse events (SAE), health related quality of life (HQOL), neutropenia, infection, withdrawal due to adverse events, myelotoxicity, anemia, thrombocytopenia, hepatitis or elevated hepatic transaminases, and pancreatitis, evidence was either absent, insufficient or lacked power to demonstrate significant differences between heterozygous and homozygous carriers in comparisons with noncarriers, and between themselves.

### Key Question 4 What are the costs of determining TPMT enzyme activity and/or genotyping for patients with chronic autoimmune disease being considered for thiopurine-based therapy (e.g., costs of testing, costs of care, and costs of treating drug-associated complications)?

Eleven studies relevant to question 4 were included (Table 22). The studies were conducted in Canada,204,207,210 Korea,208 Europe,83,204,211 New Zealand,205 and the U.S.A.40,206,212 Five of the included studies were costing studies,40,204,207,210,211 while the rest were cost-effectiveness analyses. All of the studies examined the costs associated with azathioprine (AZA).

Table 22 Characteristics of TPMT testing, care and drug-associated complications costs studies

Study | Country of conduct | Type of study | Population characteristics | Perspective
Prakshar 1995^40^ | USA | Costing study | Theoretical population of RA patients receiving AZA | NR
Tavadia 2000^210^ | Canada | Costing study | Based on one BP patient with AZA toxicity | NR
Marra 2002^209^ | Canada | CEA | Theoretical population of RA and SLE patients receiving AZA | Third-party payer
Oh 2004^208^ | Korea | CEA | Theoretical cohort of adults with moderate to severe RA or SLE receiving AZA | Societal
Winter 2004^83^ | Scotland | CEA | Theoretical population of 1000 patients receiving AZA for IBD | NR
Dubinsky 2005^206^ | USA | CEA | Theoretical population of adults with moderate to severe CD patients treated with steroids and AZA | Third-party payer
Sayani 2005^207^ | Canada | Costing study | IBD patients participating in a randomized controlled trial | NR
Priest 2006^205^ | New Zealand | CEA | Theoretical population of 1000 Caucasian patients with moderate to severe IBD receiving AZA | Payer’s perspective (New Zealand government and IBD patients)
Compagni 2008^204^ | Italy | SR of costing studies; costing study | Theoretical population of RA or IBD patients receiving AZA | NR
Gurwitz 2010^211^ | UK and Spain | Costing study | RA or IBD patient cohorts from Spain and the UK | NR
Hagaman 2010^212^ | USA | CEA | Theoretical population of IPF patients | NR

Abbreviations: AZA = azathioprine; BP = bullous pemphigoid; CD = Crohn’s disease; CEA = cost-effectiveness analysis; IBD = inflammatory bowel disease; IPF=idiopathic pulmonary fibrosis; NR = not reported; RA = rheumatoid arthritis; SLE = systemic lupus erythematosus; SR = systematic review; UK=United Kingdom, USA = United States of America.

One study based its information on a patient with bullous pemphigoid,210 while the other studies based their information on rheumatoid arthritis,40 inflammatory bowel disease,83,205,207 Crohn’s disease,206 rheumatoid arthritis or inflammatory bowel disease,204,211 idiopathic pulmonary fibrosis,212 and rheumatoid arthritis or systemic lupus erythematosus208,209 patients. For the costing analysis, one of the studies used the societal perspective,208 one used the payer’s perspective,205 two used the third-party payer perspective,206,209 and the rest did not report their perspective.

Costs of adverse events and care. One included study provided costs associated with treatment failure.209 This study obtained information from the Canadian provincial guide to medical fees. Treatment failure with AZA was estimated to cost $578.04 USD (2009) per rheumatoid arthritis or systemic lupus erythematosus patient. Another study provided a cost estimate for idiopathic pulmonary fibrosis disease progression, which was $15,805.94.^212^.

Costs of testing. Eight studies reported nine cost estimates for TPMT genotyping (Appendix C, Table C-26)83,204–212 Most of the genotyping cost information was obtained from public laboratories, while one was based on data from a hospital208 and another was from a literature search of studies reporting costs from private laboratories.206 The cost of obtaining a genotype test per patient ranged from $28.03 USD to $617.03 USD (2009). The highest cost was to obtain the TPMT genotype test from private laboratories.206 Excluding the costing item from the private laboratory, the average cost for the genotype test per patient was $89.94 USD (Figure 39). One study also provided other costing estimates related to TPMT genotyping.204 The pharmacogenetic kits for detecting TPMT*1, *2, *3A, *3B, *3C cost $46.25 USD/patient, pharmacogenetic kits for detecting TPMT*2, *3A, *3B, *3C cost $29.43 USD/patient.204

Figure 39 Costs of genotype test per patient from public laboratory data in USD (2008), in chronological order

Figure 39 depicts a bar chart of costs of genotype per patient from public laboratory data in U.S. dollars (in 2008), in chronological order. The results are that in the year 2000, the cost was $100.88, according to Tavadia; in 2002, $100.88, according to Marra; in 2004, $60.02 according to Winter; in 2004 $131.51, according to Oh; and in 2006, $94.48, according to Priest.

Four studies provided five estimates for the cost of TPMT phenotyping,205,207,211,212 which were obtained from laboratories or the government. The cost of obtaining the TPMT phenotype test per patient ranged from $46.36 to $320.98. It was not reported where the highest cost was obtained. Excluding the highest cost, the average cost for TPMT phenotyping per patient was $53.13 (Figure 40).

Figure 40 Costs of phenotype test per patient from public laboratory data in USD (2009), in chronological order

Figure 40 depicts a bar chart of costs of phenotype per patient from public laboratory data in U.S. dollars (in 2009), in chronological order. The results are that in the year 2005, the cost was around $48.00, according to Sayani; in 2006, around 45.00, according Priest; and in 2009, nearly $60.00, according to Gurwitz.

Costs of treating azathioprine-related complications. Seven of the included studies reported eight cost estimates related to the costs associated with treating AZA-related complications (Appendix C, Table C-27).40,83,205,208–210,212 All costs were obtained from hospitals or from government agencies. In order to compare across studies, the one-time cost of adverse events associated with AZA were computed.204 This cost was substantial and ranged from $1,366.82 to $7,110.02 USD (2009) (Figure 41). The average one-time cost of AZA-induced adverse events was $4,019.29.

Figure 41 One-time cost estimates of adverse events associated with AZA in USD (2009), in chronological order

Figure 41 depicts One-time cost estimates of adverse events associated with azathiopurine in U.S. dollars in the year 2009, in chronological order. The results are that in the year 1995, the cost was around $2,800.00, according to Prakshar; in 2000, around $7,000.00 according to Tavadia; in 2002, around $1800.00, according to Marra; in 2004, around $3,000.00 according to Winter; in 2004, around $3,600.00 dollars according to Oh; in 2006, around $6,000.00 according to Priest; and in 2010, around $5,800 according to Hagaman.

One study reported the costs of leucopenia leading to death, which was $15,691.46.^212^ In addition, another study reported two cost estimates for the average cost per identified TPMT-deficient individual, which was $11,982.10 in a hospital in the United Kingdom and $11,714.92 in UCB Pharma in Spain.211

Key points. The costs related to TPMT genotyping range from $28.03 to $617.80 USD (2009). This heterogeneity was likely due to different methodological choices.

TPMT phenotyping usually costs less than TPMT genotyping and ranges from $46.36 to $320.98. Similar to TPMT genotype testing costs, the heterogeneity observed across studies likely reflected methodological choices.

The one-time cost of adverse events associated with AZA was substantial, ranging from $1,366.82 to $7,110.02 across studies.

The costs related to identifying a TPMT-deficient individual is approximately $11,848.51.

#### Survey of Laboratories Conducting Analyses of TPMT Enzymatic Activity and Genotyping

Responses were received from six out of the seven laboratories that were sent a link to the online questionnaire: three in Canada; and three in the United Kingdom. Results are summarized in Table 23.

Table 23 Laboratory questionnaire responses

Questionnaire item | Answer | | N affirmative responses
Thiopurine methyltransferase (TPMT) analyses | Phenotyping, with low enzymatic activity specimens referred to external laboratory for genotyping | | 2
Thiopurine methyltransferase (TPMT) analyses | Genotyping only | | 1
Thiopurine methyltransferase (TPMT) analyses | Both genotyping and phenotyping | | 3
TPMT analytical method | Enzymatic activity assay | Mass spectrometry | 1
TPMT analytical method | Enzymatic activity assay | HPLC | 3
TPMT analytical method | Genetic analysis | PCR/RFLP | 2
TPMT analytical method | Genetic analysis | Sequencing | 2
TPMT analytical method | Genetic analysis | Site-directed PCR | 2
Alleles targeted in mutation specific genetic analysis | TPMT*2, *3A, *3B, *3C | | 3
Alleles targeted in mutation specific genetic analysis | TPMT*2, *3A, *3C | | 1
Alleles targeted in mutation specific genetic analysis | TPMT*3A, *3B, *3C | | 1 (external lab)
Alleles targeted in mutation specific genetic analysis | TPMT*3A | | 1
Yearly TPMT testing volume | Enzymatic activity assay | 600 | 1
Yearly TPMT testing volume | Enzymatic activity assay | 3000 | 1
Yearly TPMT testing volume | Enzymatic activity assay | 4000 | 1
Yearly TPMT testing volume | Enzymatic activity assay | 15,000 | 1
Yearly TPMT testing volume | Enzymatic activity assay | 19,000 | 1
Yearly TPMT testing volume | Genetic analysis | 50 | 1
Yearly TPMT testing volume | Genetic analysis | 550 | 1
Yearly TPMT testing volume | Genetic analysis | 1500 | 1
Yearly TPMT testing volume | Genetic analysis | Unknown referrals for low enzymatic activity samples | 1
Preferred specimen for analysis | EDTA whole blood | | 6
Preanalytical requirements a) Specimen stability prior to analysis | 24–48 Hr at (4°C) | | 1
Preanalytical requirements a) Specimen stability prior to analysis | Stable 4 days (temperature not specified) | | 1
Preanalytical requirements a) Specimen stability prior to analysis | Stable 5 days at room temperature | | 1
Preanalytical requirements a) Specimen stability prior to analysis | Stable 1 week at room temperature | | 1
Preanalytical requirements a) Specimen stability prior to analysis | Stable 8 days refrigerated (4°C) | | 1
Preanalytical requirements a) Specimen stability prior to analysis | N/A | | 1
Preanalytical requirements b) List of patients’ current medications | No | | 5
Preanalytical requirements b) List of patients’ current medications | Yes | | 1
Internal quality control | Positive and negative controls with each run | | 4 (2 specify duplicates)
Proficiency of TPMT analyses | Enzymatic activity analysis repeatability | Within runs: 3–10% | 4
Proficiency of TPMT analyses | Enzymatic activity analysis repeatability | Between runs: 5–20% | 5
Proficiency of TPMT analyses | Genotyping concordance: | 100% (comparator not reported) | 1
Proficiency of TPMT analyses | Genotyping concordance: | 97% -100% (compared with phenotyping, overall) | 2
Proficiency of TPMT analyses | Genotyping concordance: | 60% for intermediate carrier samples | 1
External quality control | Yes (externally supplied/exchanged unknowns) | | 2
External quality control | No | | 4
Abnormal results called to the physician | Yes | | 6 (1 calls only for homozygotes)
Abnormal results called to the physician | No | | 0
Reference intervals for TPMT enzymatic activity | Deficient <5 U/g Hb | | 1
| Deficient <19.2 U/g Hb | | 1
| Low 6–34 U/g Hb | | 1
| Low <10 U/g Hb | | 2
| Carrier 11–25 U/g Hb | | 1
| Intermediate 10–35 U/g Hb | | 1
| Heterozygous 19.2–33.7 U/g Hb | | 1
| Normal 26–50 U/g Hb | | 1
| Normal 38.5–62.5 U/g Hb | | 1
| Normal 35–79 U/g Hb | | 1
| Normal >35 U/g Hb | | 1
| High >80 U/g Hb | | 1
Highlight suspected heterozygous patients from enzymatic assay | Yes | | 4
Highlight suspected heterozygous patients from enzymatic assay | No | | 1
Highlight suspected heterozygous patients from enzymatic assay | N/A | | 1
Turn around time for testing | 1–2 days | | 1
Turn around time for testing | 1 week | | 4
Turn around time for testing | <3 weeks | | 1
Charges associated with laboratory testing | Enzymatic activity - £33/Genotyping - £96 | | 1
Charges associated with laboratory testing | Enzymatic activity - £29 (the price includes genotyping if required) | | 1

Abbreviations: EDTA = ethylenediaminetetraacetic acid; HPLC = high performance liquid chromatography; N/A = not applicable; PCR/RFLP = polymerase chain reaction/restriction fragment length polymorphism TPMT = thiopurine methyltransferase; U/g Hb = Units per gram of hemoglobin = nanomoles of product per hour per gram hemoglobin.

Among the responding laboratories, yearly volumes of TPMT measurements range from 50 to 1500 for allelic determinations, and from 600 to 19,000 for enzymatic activity analyses.

Analytical methodologies. One laboratory conducts only genotyping and two laboratory conduct only phenotyping. The two labs also refer samples to other laboratories for genotyping. One lab refers out low enzymatic activity (i.e. below 10 U/g Hb) specimens for confirmatory genotyping. The other three laboratories conduct both types of analyses.

Between one and four specific genotypes are determined: TPMT*2 (four laboratories); TPMT*3A (six laboratories); TPMT*3B (four laboratories); and TPMT*3C (five laboratories). Genotype determination is performed by polymerase chain reaction/restriction fragment length polymorphism (PCR/RFLP), genetic sequencing and site-directed PCR. The methods are equally popular, each being used by two laboratories.

TPMT enzymatic activity is determined on red blood cell (RBC) lysates using enzymatic assay followed by high performance liquid chromatography (HPLC) (three laboratories), or mass spectrometry (one laboratory). Three laboratories report results as nmol/g Hb/h, and one laboratory reports results as pmol/h/mg Hb. Both are numerically equivalent to 1 U/g Hb, the unit we are using in the present report.

Preanalytical requirements. All laboratories collect whole blood, with EDTA anticoagulant. Specimens are stored at 4^o^C or room temperature for between one and eight days.

One of the laboratories requires a list of patients’ current medications prior to conducting analyses.

Quality control. All six participating laboratories report a procedure for internal quality control, which involves the inclusion of positive and negative controls within each run, in some cases in duplicate (two laboratories report conducting multiple runs per day). Results of internal quality control procedures are similar across participating laboratories, with enzymatic analysis repeatability ranging from three to ten percent within runs, and from five to ten percent between runs. Two of the laboratories conducting both genotyping and phenotyping analyses reported between 95 and 100 percent concordance between genotyping and phenotyping overall. One laboratory clarified that concordance was lower (60 percent) for intermediate carriers.

Positive and negative internal control samples are obtained from known staff, patients or pooled known samples.

Two of the six laboratories participate in external quality assurance, consisting of either specimen exchange with a comparable laboratory or participation in a formal external quality assurance program. The United Kingdom National External Quality Assessment Service has received funding for global availability for TMPT activity analyses in 2010.

Reporting of results. All of the laboratories report abnormal results to the responsible physician; however, one laboratory only reports homozygous (severe deficiency) results. Furthermore, of the five laboratories that perform enzymatic activity analyses, four also highlight suspected heterozygous patients.

Enzymatic activity reference intervals differ between laboratories. Three laboratories employ three reference intervals with two of the laboratories defining the intervals as: (low, intermediate and normal) and one laboratory defining them as: (normal, heterozygous, deficient); One laboratory uses four reference intervals (deficient, low, normal and high). Two laboratories define low activity as below 10 U/g Hb, while the third defines low activity as between 6 and 34 U/g Hb. Two laboratories define normal activity as above 35 U/g Hb, while three other laboratories define normal activity as between 26 and 50 U/g Hb; between 25 and 120 U/g Hb; and between 38.5 and 62.5 U/g Hb respectively. The two laboratories that include a deficient interval define deficient TPMT activity as below 5 U/g Hb and below 19.2 U/g Hb. The laboratory that includes a heterozygous interval defines heterozygous as between 19.2 – 33.7 U/g Hb. Finally the laboratory that includes a high reference interval defines high TPMT activity as above 80 U/g Hb. In each case, reference intervals have been determined by the individual laboratories from large population-based studies.

Analysis turnaround times range from one day to less than three weeks, with four labs reporting a turnaround time of a week.

Costs associated with testing. Two laboratories reported on costs of testing. One reported a cost of £29 for both TPMT enzymatic activity plus genotyping if required for low activity values. The other charges £33 for TPMT enzymatic activity and £96 for genotyping.

Key points. A questionnaire, developed with expert input, was completed by six laboratories that provide TPMT analytic services, in Canada and the United Kingdom.

The preferred specimen type across laboratories is whole blood, with EDTA anticoagulant. Specimens are stored at 4^o^C or room temperature for between one and eight days.

Each laboratory follows a procedure for internal quality control. Two also participate in external quality control programs.

Enzymatic analysis repeatability ranges from three to ten percent within runs, and from five to 20 percent between runs.

Genotyping concordance with phenotyping up to 100 percent has been reported, although lower concordance was reported for intermediate carriers.

Analysis turnaround times range from one day to less than three weeks.

All laboratories report abnormal results to the responsible physician on an urgent basis.