# Methods

(see Methods Update)

## Literature Search Strategies and Peer Review of Electronic Search Strategies

(See Search Update)

Electronic search strategies were developed and tested through an iterative process by an experienced medical information specialist (BS) in consultation with the team. The search strategy was peer reviewed by RD according to the PRESS guideline.33 The following databases were searched: Ovid MEDLINE® 1950 to May Week 3 2010; The Cochrane Library® (CLIB 2009 3) including CENTRAL, CDSR, DARE, HTA, and NHSEED; BIOSIS® May 6 2009; EMBASE® 1980 to 2010 Week 21; Genetics Abstracts: May 7 2009; and Ovid Healthstar 1966 to April 2010. EconLit^TM^ was searched May 7 2009 for the economics section (question 4). Strategies utilized a combination of controlled vocabulary and keywords. No language or date restrictions were imposed on any of the searches and animal studies were excluded. Additional references were identified through scanning reference lists of relevant articles, and by expert nomination. Grey (unpublished, unindexed or difficult to locate) literature were sought through searching the websites of relevant specialty societies and organizations. The detailed search strategies are available in Appendix A.

## Study Selection

We employed three levels of screening of retrieved records. Study selection was based on predefined eligibility criteria of interventions (testing and treatment), patient populations, outcome measures, and study design (Table 3). Studies that included patients reporting to a clinic then tested their TPMT genotype or phenotype to correlate with AEs in which adverse events were noted from patients charts were considered cross-sectional in design. The electronic literature search and expert-nominated records were uploaded to the software program EPPI-Reviewer 3.0,^34^ along with screening questions developed by the review team. Titles and abstracts were screened by one reviewer for potential relevance, and exclusions at this level were verified by a second reviewer. In case of disagreement or uncertainty about relevance, the record was passed through to the next level for full-text review. Two reviewers reviewed full text reports independently, applying a priori eligibility criteria. Discrepancies were resolved through discussion and consensus or by third party adjudication if consensus could not be reached. Reviewers were not masked to the reports’ authors, institution or journal. For key questions 1a and 1b, a third level of screening was undertaken by content experts (RB and EL) to confirm records marked as relevant at a relatively liberal level II screening. Records that were unavailable as abstract or full text reports, or were commentaries, letters, editorials and reviews were excluded. Only articles in the English language were eligible.

Table 3 Study selection criteria

Criterion | Key question | Included | Excluded | Eligible study design
Patient population | All key questions | Patients with chronic autoimmune diseases, of any age | Cancer, organ transplant | -
Drug treatment(s) | All key questions | Azathioprine (AZA), and 6-mercaptopurine (6-MP) | 6-thioguanine, excluded because it is not metabolized by the TPMT enzyme | -
Test(s) | All key questions | 1. TPMT enzymatic activity as determined by HPLC, radioassay or mass spectrometry; 2. Genotyping using PCR, direct sequencing or RFLP | Mass quantitation was excluded because it is rarely used | -
Outcomes | 1a | Specimen types and collection procedures, lab transportation, interference of coadministered drugs, patient preparation and identification, enzyme stability, and factors affecting preanalytic enzymatic variability (e.g. gender, age, comorbid conditions etc.) | - | Any
Outcomes | 1b | Inter-, and intra-assay coefficients of variations and/or test concordance | - | Any
Outcomes | 1c | Testing sensitivity and specificity | - | Any
Outcomes | 2 | Patients requiring thiopurine dose reduction, patients switching to nonthiopurine treatment, and number of specific monitoring tests per person time at risk, or per patient per unit treatment time | Differences in efficacy (i.e. clinical response to treatment) | Randomized controlled trials, controlled clinical trials, cohort, and case- control studies reporting numerical data in which administration of thiopurine treatment followed thiopurine status testing and was adjusted or replaced (by another disease modifying treatment) in at least one group
Outcomes | 3a | Mortality, infection, hospitalization (including ICU admissions if available), withdrawal due to adverse events (WDAE), serious adverse events (SAE), Health-related quality of life measures (HQOL) | Differences in efficacy (i.e. clinical response to treatment)
Outcomes | 3b | Myelotoxicity (two or more of leukopenia, thrombocytopenia, and anemia), leukopenia, neutropenia, thrombocytopenia, and anemia, hepatoxicity (raised ALT/AST) and pancreatitis | Differences in efficacy (i.e. clinical response to treatment)
Outcomes | 3c | Mortality, hospitalization (including ICU admissions if available), withdrawal due to adverse events (WDAE), serious adverse events (SAE), Health-related quality of life measures (HQOL), myelotoxicity (two or more of leukopenia, thrombocytopenia, and anemia), leukopenia, neutropenia, thrombocytopenia, anemia, hepatoxicity (raised ALT/AST) and pancreatitis | | Any study design in which thiopurine treatment was not guided by prior knowledge of TPMT status
Outcomes | 4 | Costs of testing, costs of care, costs of treating drug-associated complications | Economic analyses (e.g., cost analysis, cost-benefit analysis, cost-effectiveness analysis, cost-utility analysis) | Studies that provide costing data
Publication status | All key questions | | NonEnglish publication, editorial, review, commentary, letter, news report or case report. Also records unavailable as abstracts or full text reports

Abbreviations: 6-MP = 6-mercaptopurine; AZA = azathioprine; HQOL = Health-related quality of life; ICU = intensive care unit; PCR = polymerase chain reaction; RFLP = restriction fragment length polymorphism; WDAE = withdrawal due to adverse events; SAE = serious adverse events; TPMT = thiopurine methyltransferase

## Data Extraction

Sample data extraction forms are presented in Appendix B. Where applicable for a key question, we extracted the following data from studies: first author’s name, year of publication, country, study design (prospective or retrospective), sample size, eligibility criteria, population characteristics, type of genetic testing (e.g. alleles tested, method of testing and source of DNA) and enzymatic assay, testing thresholds, percentage of nondiagnostic results, deviation from Hardy-Weinberg equilibrium (HWE), reported sensitivity and specificity, drug treatment and dose, definitions of outcomes, number of patients with and without events as dichotomous outcomes data for a given genotypic or phenotypic enzymatic status, adjusted and crude effect estimates with standard error or confidence intervals, validation of health profiles, coefficient of variations, preanalytic variables for TPMT activity, costing items (e.g., costs of adverse events, cost of testing, costs of care, currency, discount rate, source of cost data) and determinants of preanalytic validity as reported in papers.

For the diagnostic accuracy question, numerical and meta-analyzable data were extracted in two 2×2 tables as shown in Table 4. Patients tested negative for any of the SNPs were considered noncarriers (wild type homozygous), while carriers were either heterozygous for the variant allele or homozygous for it. For data clarification and missing data we wrote to study authors. Heterozygous carrier state implied presence of one variant allele on one of the two paired chromosomes; homozygous state implied presence of one of the same variant alleles on each one of the two paired chromosomes, or presence of two different mutant alleles on each of the two paired chromosomes (the latter is also called a compound heterozygous state). In other words, compound heterozygosity was extracted and interpreted as homozygous carrier data. We did not differentiate between normal and high TPMT activities, and most studies used the terms interchangeably. When investigators reported raw data, we considered TPMT activity of less than 5.0 Units per milliliter of packed red blood cells (U/mL RBCs) as low, between 5.0 and 13.5 U/mL RBCs as intermediate, and greater than 13.5 U/mL RBCs as normal activity. Extracted data were verified and corrections made where necessary. For clarity of presentation, we standardized and presented TPMT activity data according to two standard units, U/mL RBCs or U/gram of hemoglobin (g Hb). Note that 1 Unit is equivalent to 1 nanomole of product per hour (nmol/h), and 1 nmol/h/g Hb is equivalent to 1 pmol/h/mg Hb. Unless otherwise stated, the product was 6-MMP.

Table 4 Two by two tables for analysis of diagnostic accuracy

2×2 Table A
| | Phenotyping (enzymatic activity assay) Reference standard
| | Normal or high activity | Intermediate or low activity
Genotyping Index test | Heterozygous or homozygous carriers
Genotyping Index test | Noncarriers

2×2 Table B
| | Phenotyping (enzymatic activity assay) Reference standard
| | Intermediate, normal, or high activity | Low activity
Genotyping Index test | Homozygous carriers
Genotyping Index test | Noncarriers or heterozygous carriers only

When there were multiple reports of the same study we referenced the most relevant record as the primary identifying study, and also extracted additional data as available from companion report(s).

## Assessment of Risk of Bias

For key questions 1c (diagnostic accuracy); 2, 3a, and 3b (effectiveness of testing versus no testing;) and 3c (association studies), we assessed risk of bias of studies using standard questionnaires.

For diagnostic studies we used a modified QUADAS tool35 in which we replaced the item number 4 about the time period between the two tests with an item questioning whether Hardy-Weinberg equilibrium (HWE) was tested or not.

For randomized controlled trials and cohort studies we assessed the following:

- similarity of groups at baseline in terms of baseline characteristics and prognostic factors
- extent to which outcomes were described
- blinding of subjects and providers
- blinded assessment of the outcome
- intention-to-treat analysis
- differential loss to follow-up between the compared groups or overall high loss to follow-up,
- Potential for financial conflict of interest

For trials, two additional elements were considered:

- methods used for randomization and
- allocation concealment
- Treatment adherence

For cohort studies, yet another set of elements was considered:

- sample size
- methods for selecting participants (inception cohort, methods to avoid selection bias);
- methods for measuring exposure variables
- methods to control confounding (e.g. design features of matching or restriction to particular subgroups; and analytic methods of stratification or regression modeling with propensity scores or covariates)
- appropriateness of methods of measuring TPMT status

For key question 3c, risk of bias items included assessment of comparability of groups, blinded assessment of outcome and categorization of TPMT genotyping or phenotyping testing results, sample selection and survival bias, adequacy of description of TPMT testing methodology and its reliability, reporting of ambiguous and uninterpretable results of TPMT testing, compliance with thiopurine treatment, sources of TPMT genotyping or phenotyping for all patients, loss to followup, clear description of outcomes definitions, adequacy of sample size, methods to control for confounding, potential for financial conflict of interest, and finally assessment of HWE and gene-gene interaction where applicable.

Each study was given an overall risk of bias assessment of Good (low risk of bias), Fair or Poor (high risk of bias) (Table 5). Because of a lack of standards for assessment of risk of bias or quality of preanalytic, analytic, postanalytic, and costing data studies, risk of bias was not assessed for key questions 1a, 1b, 1d and question 4. To rate the strength of the body of evidence, we planned to qualify the corpus of evidence into low, medium and high risk for an outcome of interest. Since only one study contributed to the outcomes preplanned for rating the strength of evidence, individual risk of bias of this study determined the overall risk of bias of the evidence for those outcomes in form of a single study. In other words, fair risk of bias of the individual study for the outcomes determined the medium risk of bias of the available evidence. Details of items contributing to risk of bias assessment for each study are reported in Appendix C (Evidence tables).

Table 5 Categorization of overall risk of bias of individual studies

[underlined: Good (low risk of bias).] These studies have the least bias and results are considered valid. A study that adheres mostly to the commonly held concepts of high quality including the following: a formal randomized controlled study; clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; low dropout rate; and clear reporting of dropouts
[underlined: Fair.] These studies are susceptible to some bias, but it is not sufficient to invalidate the results. They do not meet all the criteria required for a rating of good quality because they have some deficiencies, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems
[underlined: Poor (high risk of bias).] These studies have significant flaws that imply biases of various types that may invalidate the results. They have serious errors in design, analysis, or reporting; large amounts of missing information; or discrepancies in reporting.

## Evidence Synthesis and Analysis

For key questions 1a, 1b, and 4, evidence was synthesized qualitatively.

Data synthesis was not possible for key questions 1d due to lack of evidence, and for question 2, 3a and 3b sparse evidence precluded evidence synthesis.

For key question 4, costing data were converted to United States Dollar 2009 values using purchasing power parities36 and were inflated to reflect 2009 values using the consumer price index for US medical care for all urban consumers (series identification # CUUR0000SAM).37

For the main quantitative syntheses, we did not consider underlying autoimmune disease, method of genotyping or phenotyping (i.e. enzymatic activity testing), population demographics, and the different observational study designs, as contributors to any important clinical or methodological diversity. In this light, the underlying assumption was that differences in outcomes of thiopurine toxicity are explained by differences in TPMT enzymatic activities across similar doses of the drugs. We used DerSimonian and Laird’s random-effects model for pooling individual study estimates, weighting them by individual study variance and the estimated between-study heterogeneity. We pooled whenever there were two studies in a given analysis for an outcome. Pooled estimates of diagnostic sensitivity and specificity percentages, and odds ratios and their 95 percent confidence intervals were calculated using CMA software (version 2.2.046).

Despite the underlying assumption, we planned to explore clinical and methodological diversity in a random effects univariate meta-regression based upon preidentified covariates of study design, overall risk of study bias, TPMT testing methodology, specific age subgroups, and underlying autoimmune disease(s) subgroups. Data on variables such as racial groups were too sparse to be considered as covariates. HWE was not considered as a covariate because it has been shown that including studies that appear to violate the HWE in the meta-analysis does not bias the summary estimates.38 Enzymatic activity cutoffs used in the studies differed trivially between them. This variability is not unexpected because laboratories employ in-house reference intervals based on slight population and assay differences. As such, the TPMT enzymatic activity cutoff was also not considered to be an important effect modifier. For key questions other than the diagnostic question 1c, an additional covariate considered was blinded assessment of outcomes and TPMT status (by genotyping or phenotyping). Meta-regression was done in SAS using the NLMIXED procedure whenever six or more studies were involved in the pooled result of a binary covariate and 12 or more if the covariate had three distinct levels. When possible, we tested for statistical heterogeneity using Cochran’s Q and reported it when found to be substantial (p value for chi-squared test of heterogeneity less than 0.10, and I^2^ greater than or equal to 50 percent).

### Pooling of Evidence of Diagnostic Accuracy (Key Question 1c)

We considered the TPMT enzymatic activity assay as the reference for the index test of genotyping of the different SNPs. Since the index test reported presence or absence of variant allele as a dichotomous outcome, implicit or explicit cut-off threshold effects were ruled out. We, therefore, pooled for the outcomes of test sensitivity and specificity instead of summary receiver-operating characteristics.

The role of testing for statistical heterogeneity in effect estimates from studies of diagnostic accuracy is less well understood. Since the estimates of sensitivity and specificity are interrelated, the significance of heterogeneity in one and not the other is unclear. We, therefore, did not formally test for the extent of statistical heterogeneity; however, we did carry out univariate meta-regression based upon preidentified covariates stated above when possible.

Since studies identified homozygous and heterozygous carrier states by testing for different TPMT variant alleles, we pooled only the studies testing for the same set of SNPs.

When possible, two meta-analyses were considered for each set of variant alleles investigated by at least two studies. In meta-analysis 1, genotypes were dichotomized into noncarriers and carriers (or homozygotes and/or heterozygotes) and phenotypes were dichotomized into normal (or high) and subnormal (or intermediate and/or low and/or absent) enzymatic activities. In meta-analysis 2, we dichotomized genotypes into noncarriers and/or heterozygotes and homozygotes, and phenotype into normal and/or high and/or intermediate and low/absent activities (Table 6). For studies with 100 percent sensitivity or specificity, 0.5 was added to either both TP (true positive) and FN (false negative) or TN (true negative) and FP (false positive), in order to estimate pooled proportions.

Table 6 Meta-analyses 1 and 2, for Key Question 1c

Meta-analysis 1
| Normal/high activity | Intermediate/low/absent activity | Sensitivity 1 | Specificity 1
Homozygotes and/or heterozygotes | A1 | B1 | B1/(B1+D1) | C1/(C1+A1)
Noncarrier (or Wild types) | C1 | D1 | B1/(B1+D1) | C1/(C1+A1)

Meta-analysis 2
| Normal/high/intermediate activity | Low/absent activity | Sensitivity 2 | Specificity 2
Homozygotes | A2 | B2 | B2/(B2+D2) | C2/(C2+A2)
Noncarrier (or Wild types) and/or heterozygotes | C2 | D2 | B2/(B2+D2) | C2/(C2+A2)

### Pooling of Evidence of Association of Thiopurine Toxicity With TPMT Genotypic or Phenotypic Status (Key Question 3c)

Outcomes data were number of patients with and without events. With respect to genotype, we considered a codominant model in which TPMT enzymatic activities are highest when both TPMT alleles are Wild type (i.e. noncarrier state without TPMT polymorphisms), followed by somewhat decreased enzymatic activity when the one of the two alleles is mutant or variant (i.e. heterozygous carrier of mutation, or heterozygote) and lowest to absent TPMT enzymatic activities when both alleles are variants (i.e. homozygous carrier of mutation, or homozygote). The possible comparisons were heterozygotes versus noncarriers, homozygotes versus noncarriers, and homozygotes versus heterozygotes. For the association with TPMT enzymatic activity, the comparisons were intermediate enzymatic activity versus normal/high, low to absent activity versus normal/high and low/absent activity versus intermediate activity.

For estimating association with genotype, the primary analysis included all studies as long as they tested for the most common TPMT alleles, irrespective of testing additional polymorphisms. Alleles we considered most common were TPMT*2, *3A, *3B, *3C (Table 2). Secondary analyses were allele specific and restricted to only those subgroups of studies that tested specific alleles. Additionally, we assessed deviations of the genotype frequencies from those predicted by the Hardy-Weinberg law (chi-square test). A p-value less than 0.05 indicated possible genotyping error (other factors, such as inbreeding could also be at play). The Hardy-Weinberg law states that if there are 2 alleles at a particular locus, named A and a, with frequency p and q, respectively, then after 1 generation of random mating the genotype frequencies of the AA, Aa, and aa groups in the population will be p^2^, 2pq, and q^2^, respectively. Given that there are only 2 alleles possible, A or a, then p + q = 1, and p^2^ + 2pq + q^2^ = 1.

### Rating the Strength of Evidence and Assessing Applicability

For the prespecified outcomes of mortality (critical), serious adverse events (critical), myelotoxicity (important), and health-related quality of life (important) in Key Questions 3a, and 3b, two methodologists rated the strength of the body of evidence across the domains of risk of bias, consistency, directness and precision as per published guidance.39 Disagreements were resolved by consensus. Applicability was assessed according to the domains of patient population, intervention and dose, comparator, outcome and study duration. We examined eligibility criteria, participant demographics, and distribution of genotype to assess generalisability of population. To assess applicability of testing we examined the type of TPMT tests employed and their validity and reproducibility. We also ascertained dose and type of thiopurine. We also examined whether non-pretested group of patients received routine blood count monitoring or not, and the study duration.

## Survey of Laboratories Conducting TPMT Analyses

To supplement the limited published literature to answer key questions 1a, 1b, 1c, and 1d, further data regarding the preanalytical and postanalytical requirements and performance characteristics of TPMT laboratory analyses was collected. With advice from the Technical Expert Panel, the review team decided to survey laboratories that provide TPMT analytical services.

Our target population included all laboratories in which medium of language was English and provide TPMT analytical services. Potential participating laboratories were identified by the Technical Expert Panel, which also queried two listservs: Clinical Chemistry General Topics (American Association for Clinical Chemistry) and CSCC Listserv (Canadian Society of Clinical Chemists). Based on these expert recommendations, two organizations and seven laboratories were contacted to determine their willingness either to complete a questionnaire or to disseminate the questionnaire to other relevant laboratories. Contact was initiated using an emailed letter explaining the intent behind the request, as well as background information on the questionnaire. The letter and questionnaire are included in Appendix B.

The review team developed a draft questionnaire, which was assessed by the Technical Expert Panel for face validity and comprehensiveness and the logical flow of questions and responses were ensured for both paper and electronic versions. The questionnaire was also revised after some initial responses revealed ambiguity. The final questionnaire included 11 questions with multiple subquestions relating to TPMT analytical methods (e.g., sample type and handling), preanalytical requirements (e.g., specimen stability), quality control procedures, reporting of results and cost of TPMT services. The questionnaire took approximately 15–20 minutes to complete. The full questionnaire is included in Appendix B.

The survey was administered electronically via Survey Monkey^TM^ to representatives of the six laboratory representatives who had agreed to participate, with up to three weeks provided for completion. Reminder emails were sent one week after initial contact as well as three days before responses were due. Responses were captured in a Survey Monkey^TM^ database and were subsequently downloaded to Microsoft Excel to conduct the analysis. We conducted a descriptive analysis, and summarized results using frequencies and ranges as appropriate.

Ethics approval was obtained from the Ottawa Hospital Research Ethics Board before initial contact with any potential participating laboratory.