# Additional Acknowledgements

The UO-EPC gratefully acknowledges the following individuals who served on our Technical Expert Panel (TEP). Acknowledgment does not reflect endorsement of this report.

Dr. Thomas Trikalinos, MD, PhD

Co-Director

Evidence-Based Practice Centre

Tufts University

Boston, MA

Dr. Marc S. Williams, MD

Director

Intermountain Healthcare Clinical Genetics

Institute

Salt Lake City, UT

Dr. Jonathan Berg, PhD

Director, Divison of Pathology

Clinical Biochemistry

City Hospital

Birmingham, UK

Dr. Peter Bunting, PhD

Associate Professor/Clinical Biochemist

University of Ottawa/The Ottawa Hospital

Ottawa, ON

The UO-EPC gratefully acknowledges the following individuals who peer reviewed the initial draft of this report. Acknowledgment does not reflect endorsement of this report.

Dr. Marta Gwinn, MD, M.P.H.

Associate Director for Epidemiology

National Office of Public Health Genomics

Center for Disease Control and Prevention

Atlanta, GA

Dr. Marc S. Williams, MD

Director

Intermountain Healthcare Clinical Genetics

Institute

Salt Lake City, UT

Dr. Loralie Langman, PhD

Associate Professor

Department of Laboratory Medicine & Pathology

Mayo Clinic

Rochester, MN

Dr. Nicolas von Ahsen, PhD

Department of Clinical Chemistry

University of Göttingen

Göttingen, Germany