# Excluded Studies

## Level II Exclusions by reasons (for all 334 excluded records)

### Exclude on record type (editorial, review, commentary, letter, news, report or case report), n=44

17th IFCC-FESCC European Congress of Clilnical Chemistry and Laboratory Medicine/60th National Congress of the Netherlands-Society-for-Clinical-Chemistry-and-Laboratory-Medicine (EUROMEDLAB 2007). Amsterdam, NETHERLANDS. June 03 -07, 2007. Clinical Chemistry and Laboratory Medicine. S7. 2007;45(Suppl S):S5-S9. S5. SS448.
43rd Annual Meeting of the Academy-of-Clinical-Laboratory-Physicians-and-Scientists. Philadelphia, PA, USA. June 05 –07, 2008. American Journal of Clinical Pathology. 2008;130(3):469-91.
Abbott A. With your genes? Take one of these, three times a day.[erratum appears in Nature. 2003 Sep 25;425(6956):337]. Nature. 10. 23. 2003;425(6960):760-2. [pmid: 14574377].
Allorge D, Hamdan R, Broly F, et al. ITPA genotyping test does not improve detection of Crohn’s disease patients at risk of azathioprine/6-mercaptopurine induced myelosuppression. Gut. 2005;54(4).
Barstad P. Method of determining thiopurine methyltransferase activity. Official Gazette of the United States Patent and Trademark Office Patents. 2003;1271(2).
Bruns T, Stallmach A. Drug monitoring in inflammatory bowel disease: helpful or dispensable? [Review] [117 refs]. Digestive Diseases. 2009;27(3):394-403. [pmid: 19786771].
Buster EH, van Vuuren HJ, Zondervan PE, et al. Thiopurine-methyltransferase and inosine triphosphate pyrophosphatase polymorphism in a liver transplant recipient developing nodular regenerative hyperplasia on low-dose azathioprine. European Journal of Gastroenterology & Hepatology. 01. 2008;20(1):68-72. [pmid: 18090994].
Cheung ST, Allan RN. Mistaken identity: misclassification of TPMT phenotype following blood transfusion. European Journal of Gastroenterology & Hepatology. 11. 2003;15(11):1245-7. [pmid: 14560161].
De Boer NK, Gilissen LP, Derijks LJ, et al. Hepatotoxicity of long-term and low-dose 6-thioguanine in IBD patients. Gastroenterology. 2006;130(4, Suppl 2):A202-A203.
Derijks LJ, Hommes DW. Thiopurines in inflammatory bowel disease: new strategies for optimization of pharmacotherapy?. Current Gastroenterology Reports. 2006;8(2):89-92. [pmid: 16533469].
Derijks LJJ, Wong DR. Pharmacogenetics of thiopurines in inflammatory bowel disease. Current Pharmaceutical Design. 2010;16(2):145-54. [pmid: 20205660].
Dubinsky MC. Monitoring of AZA/6-MP treatment in children with IBD is necessary. Inflammatory Bowel Diseases. 2003;9(6):386-8. [pmid: 14671488].
Escousse A, Mousson C, Santona L, et al. Azathioprine-induced pancytopenia in homozygous thiopurine methyltransferase-deficient renal transplant recipients: a family study. Transplantation Proceedings. 1995;27(2):1739-42. [pmid: 7725481].
Ford L, Berg J. Adverse reactions to azathioprine. Internal Medicine Journal. 2009;39(12):859-60. [pmid: 20233255].
Ford LT, Berg JD. Thiopurine S-methyltransferase (TPMT) assessment prior to starting thiopurine drug treatment; a pharmacogenomic test whose time has come. Journal of Clinical Pathology. 2010;63(4):288-95. [pmid: 20354201].
Fotoohi AK, Coulthard SA, Albertioni F. Thiopurines: Factors influencing toxicity and response. Biochemical Pharmacology. 2010;79(9):1211-20. [pmid: 20096268].
Frohman EM, Havrdova E, Levinson B, et al. Azathioprine myelosuppression in multiple sclerosis: characterizing thiopurine methyltransferase polymorphisms. Multiple Sclerosis. 2006;12(1):108-11. [pmid: 16459728].
Gasche C, Grundtner P. Genotypes and phenotypes in Crohn’s disease: Do they help in clinical management?. Gut. 2005;54(1):162-7. [pmid: 15591523].
Gearry R, Barclay M, Gardiner S, et al. 6-thioguanine nucleotides and thiopurine methyltransferase activity: important factors determining response to treatment and incidence of adverse effects from azathioprine and 6-MP. New Zealand Medical Journal. 2003;116(1178):U531. 2003. [pmid: 12897892].
George P, Roberts R, Pike L. 6-thioguanine nucleotides and thiopurine methyltransferase activity: important factors determining response to treatment and incidence of adverse effects from azathioprine and 6-MP. New Zealand Medical Journal. 07. 25. 2003;116(1178):U531. 2003. [pmid: 12901364].
Hall A, Rabello C, Jackson G, et al. Congenital deficiency of thiopurine methyltransferase as a cause of pancytopenia in patients treated with azathioprine. British Journal of Haematology. 1996;93.
Karas-Kuzelicki N, Mlinaric-Rascan I. Individualization of thiopurine therapy: thiopurine S-methyltransferase and beyond. [Review] [87 refs]. Pharmacogenomics. 2009;10(8):1309-22. [pmid: 19663675].
Katsanos KH, Vermeire S, Claes K, et al. Thiopurine methyl transferase gene single nucleotide polymorphisms in inflammatory bowel disease. Annals of Gastroenterology. 2006;19(1):18-20.
Krynetski EY, Tai HL, Yates CR, et al. Genetic polymorphism of thiopurine S-methyltransferase: clinical importance and molecular mechanisms. [Review] [60 refs]. Pharmacogenetics. 08. 1996;6(4):279-90. [pmid: 8873214].
Kutscher E, Davies G. Pharmacogenomics: has our history become modern medicine?. South Dakota Medicine: The Journal of the South Dakota State Medical Association. 2009;62(4):160-1. [pmid: 19402301].
Lichtenstein GR. Monitoring 6-mercaptopurine/azathioprine metabolite levels. American Journal of Gastroenterology. 2007;102(Suppl 1):S14-S17.
Oellerich M, von Ahsen N, Shipkova M, et al. Genotypic and phenotypic evaluations in connection with azathioprine toxicity. Toxicological Sciences. 2003;72.
Oliveira E, Quental S, Alves S, et al. Do the distribution patterns of polymorphisms at the thiopurine S-methyltransferase locus in sub-Saharan populations need revision? Hints from Cabinda and Mozambique. European Journal of Clinical Pharmacology. 2007;63(7):703-6. [pmid: 17473918].
Otterness D, Szumlanski C, Weinshilboum R. Human thiopurine methyltransferase pharmacogenetics: Identification of a novel variant allele. Journal of Investigative Medicine. 1996;44(3):248A.
Ozbek U, Sayitoglu MA, Hatirnaz O. Allelotype frequencies of TPMT (thiopurine S-methyltransferase), CYP3A4 and CYP3A5 genes in Turkish population. Leukemia (Basingstoke). 2003;17(3).
Paci D, Ibarreta D. Economic and cost-effectiveness considerations for pharmacogenetics tests: An integral part of translational research and innovation uptake in personalized medicine. Current Pharmacogenomics and Personalized Medicine. 2009;7(4):284-96.
Pavlovic S. TPMT gene polymorphisms: On the doorstep of personalized medicine. Indian Journal of Medical Research. 2009;129(5):478-80. [pmid: 19675373].
Payne K, Newman W, Fargher E, et al. TPMT testing in rheumatology: any better than routine monitoring?. Rheumatology. 2007;46(5):727-9. [pmid: 17255139].
Payne K, Newman WG, Gurwitz D, et al. TPMT testing in azathioprine: A ‘cost-effective use of healthcare resources’?. Personalized Medicine. 2009;6(1):103-13.
Ramsden S, Pushpakom S, Newman W. TARGET - predicting adverse reaction to azathioprine prescription. Journal of Medical Genetics. 2006;43.
Relling MV, Pui CH, Cheng C, et al. Thiopurine methyltransferase in acute lymphoblastic leukemia. Blood. 01. 15. 2006;107(2):843-4. [pmid: 16401827].
Roberts-Thomson IC, Butler WJ. Azathioprine, 6-mercaptopurine and thiopurine S-methyltransferase. Journal of Gastroenterology & Hepatology. 2005;20(6):955. [pmid: 15946151].
Sarij S, Islam K. TPMT testing and hepatotoxicity in the elderly. American Journal of Gastroenterology. 2008;103.
Taniguchi A, Kamatani N. Pharmacogenetic approaches to rheumatoid arthritis. Pharmacogenomics Journal. 2004;4(6):350-3. [pmid: 15249925].
Teml A, Schaeffeler E, Schwab M. Pretreatment determination of TPMT - state of the art in clinical practice. European Journal of Clinical Pharmacology. 03. 2009;65(3):219-21. [pmid: 19198820].
The Netherlands Organisation for Health Research and Development (ZonMw). Pharmacogenetic testing in the clinical setting: is screening for TPMT genotype a cost-effective treatment strategy? The first prospective randomized controlled trial within the Dutch health care system (project) (Project record). 2006. Cochrane ID: HTA-32006001365.
Tsironi E, Browne M, Rampton DS, et al. Expression of thiopurine methyltransferase in South Asians. Gut. 2003;52(6):914-5. [pmid: 12740356].
van Asseldonk DP, de Boer NKH, Peters GJ, et al. On therapeutic drug monitoring of thiopurines in inflammatory bowel disease; pharmacology, pharmacogenomics, drug intolerance and clinical relevance. Current Drug Metabolism. 2009;10(9):981-97. [pmid: 20214590].
Weinshilboum R. Methyltransferase Pharmacogenetics. Pharmacology and Therapeutics. 1989;43(1):77-90. [pmid: 2675130].

### Exclude on study population, n = 159

Aigrain EJ, Medard Y, Sica L, et al. Thiopurine methyltransferase activity in red blood cells: A phenotyping study in the French and Gabonese populations. Therapie (Paris). 1995;(Suppl).
Alves S, Amorim A, Ferreira F, et al. Thiopurine methyltransferase polymorphism; genotype-phenotype correlation analysis in a Portuguese sample. European Journal of Human Genetics. 2001;9.
Ameyaw MM, Collie-Duguid ES, Powrie RH, et al. Thiopurine methyltransferase alleles in British and Ghanaian populations. Human Molecular Genetics. 1999;8(2):367-70. [pmid: 9931345].
Andersen JB, Szumlanski C, Weinshilboum RM, et al. Pharmacokinetics, dose adjustments, and 6-mercaptopurine/methotrexate drug interactions in two patients with thiopurine methyltransferase deficiency. Acta Paediatrica. 1998;87(1):108-11. [pmid: 9510461].
Ando M, Ando Y, Hasegawa Y, et al. Genetic polymorphisms of thiopurine S-methyltransferase and 6-mercaptopurine toxicity in Japanese children with acute lymphoblastic leukaemia. Pharmacogenetics. 2001;11(3):269-73. [pmid: 11337943].
Ansari AR, Arenas M, Marinaki T, et al. Genetic Determinants of the Thiopurine Methyltransferase Intermediate Activity Phenotype. Digestive Disease Week Abstracts and Itinerary Planner. 2003.
Barlow N. Is TPMT testing cost-effective? A study of the use of a national service for TPMT in relation to the health economic debate on pharmacogenomic testing. Pathology News. 2009;(May):1-4.
Barlow N, Ford L, Berg J. Is TPMT testing cost-effective? A study of the use of a national service for TPMT in relation to the health economic debate on pharmacogenomic testing. Annals of Clinical Biochemistry. 2009;46(Suppl 1):91.
Bergan S, Rugstad HE, Bentdal O, et al. Optimization of azathioprine therapy by measuring 6-thioguanine nucleotides and methylated mercaptopurine in renal allograft recipients. Transplantation Proceedings. 1995;27(6):3426. [pmid: 8540033].
Bo J, Schroder H, Kristinsson J, et al. Possible carcinogenic effect of 6-mercaptopurine on bone marrow stem cells: relation to thiopurine metabolism. Cancer. 1999;86(6):1080-6. [pmid: 10491537].
Breen DP, Marinaki AM, Arenas M, et al. Pharmacogenetic association with adverse drug reactions to azathioprine immunosuppressive therapy following liver transplantation.[see comment][erratum appears in Liver Transpl. 2005 Sep;11(9):1150]. Liver Transplantation. 07. 2005;11(7):826-33. [pmid: 15973722].
Brouwer C, Keizer-Garritsen JJ, Lambooy LH, et al. Thiopurine methyl transferase: activity and genotyping in patients with acute lymphoblastic leukemia. Advances in Experimental Medicine & Biology. 2000;486:327-31. [pmid: 11783509].
Brouwer C, Marinaki AM, Lambooy LH, et al. Pitfalls in the determination of mutant alleles of the thiopurine methyltransferase gene. Leukemia. 2001;15(11):1792-3. [pmid: 11681423].
Brouwer C, Marinaki TM, Lambooy LH, et al. Pitfalls in the determination of mutant alleles of the thiopurine methyltransferase (TPMT) gene: Does TPMT*3B exist?. Leukemia (Basingstoke). 2001;15(3).
Candelaria M, Taja-Chayeb L, Vidal S, et al. Importance of the polymorphisms of the thiopurine S-methyltransferase gene (TMPT) determination in Mexican mestizo patients with acute lymphoblastic leukemia (ALL). Blood. 2007;110.
Cartwright C, Savage C, Lennard L. Concordance of thiopurine methyltransferase genotype and phenotype in childhood leukaemia. British Journal of Clinical Pharmacology. 2004;57(5):685-6.
Cartwright C, Vora A, Lennard L. Comparison of thiopurine dose intensity, thiopurine metabolism and neutropenia in children with acute lymphoblastic leukaemia taking thioguanine or mercaptopurine. British Journal of Clinical Pharmacology. 2008;65(6):993-4.
Catherwood M, Davison J, McMullin M. Rapid genotyping for thiopurine methyltransferase polymorphisms in patients with acute leukaemia using lightcycler PCR. Experimental Hematology (New York). 2005;33(7 Suppl 1).
Chocair PR, Duley JA, Cameron JS, et al. Does low-dose allopurinol, with azathioprine, cyclosporin and prednisolone, improve renal transplant immunosuppression?. Advances in Experimental Medicine and Biology. 1995;370:205-8. [pmid: 7660891].
Chocair PR, Duley JA, Simmonds HA, et al. Thiopurine methyltransferase activity and efficacy of azathioprine immunosuppression in transplant recipients. Advances in Experimental Medicine & Biology. 1991;309A:61-4. [pmid: 1789271].
Chocair PR, Duley JA, Simmonds HA, et al. The importance of thiopurine methyltransferase activity for the use of azathioprine in transplant recipients. Transplantation. 1992;53(5):1051-6. [pmid: 1585469].
Chrzanowska M, Kurzawski M, Drozdzik M, et al. Thiopurine S-methyltransferase phenotype-genotype correlation in hemodialyzed patients. Pharmacological Reports. 2006;58(6):973-8. [pmid: 17220558].
Coulthard S, Hogarth L, Minto L, et al. High thiopurine methyltransferase expression confers different levels of resistance with 6-thioguanine compared to 6-mercaptopurine. British Journal of Cancer. 2000;83.
Coulthard S, Minto L, Matheson N, et al. The effect of thiopurine methyltransferase activity on the survival in patients with acute leukaemia. British Journal of Cancer. 1999;80.
Coulthard S, Robson J, Howell C, et al. Relationship between thiopurine methyltransferase genotype and phenotype in normal subjects and patients with acute leukemia. Proceedings of the American Association for Cancer Research Annual Meeting. 1998;39.
Davison JE, McMullin MF, Catherwood MA. Genotyping of thiopurine methyltransferase in patients with acute leukemia using LightCycler PCR. Leukemia & Lymphoma. 2006;47(8):1624-8. [pmid: 16966276].
Dervieux T, Medard Y, Baudouin V, et al. Monitoring azathioprine therapy in pediatric renal transplant patients with red blood cell thiopurine methyltransferase. Transplantation Proceedings. 2000;32(2):361-3. [pmid: 10715440].
Dervieux T, Medart Y, Guigonis V, et al. Thiopurine S-methyltransferase (TPMT) modulates the cytotoxic and immunosuppressive effects of 6-mercaptopurine during maintenance treatment in childhood ALL. Blood. 1999;94.
Dervieux T, Medard Y, Baudouin V, et al. Monitoring azathioprine therapy in paediatric renal transplant recipients with thiopurine methyltransferase. Pediatric Research. 1999;45.
Dokmanovic L, Urosevic J, Janic D, et al. Analysis of thiopurine S-methyltransferase polymorphism in the population of Serbia and Montenegro and mercaptopurine therapy tolerance in childhood acute lymphoblastic leukemia. Therapeutic Drug Monitoring. 2006;28(6):800-6. [pmid: 17164697].
Dooley MJ, Dixon B, Poole SG, et al. Phenotyping for thiopurine therapy in clinical practice. Journal of Pharmacy Practice and Research. 2008;38(3):188-90.
Evans WE, Hon YY, Bomgaars L, et al. Preponderance of thiopurine S-methyltransferase deficiency and heterozygosity among patients intolerant to mercaptopurine or azathioprine. Journal of Clinical Oncology. 2001;19(8):2293-301. [pmid: 11304783].
Fabre MA, Jones DC, Bunce M, et al. The impact of thiopurine S-methyltransferase polymorphisms on azathioprine dose 1 year after renal transplantation. Transplant International. 2004;17(9):531-9. [pmid: 15349717].
Flowers CR, Veenstra DL. Can pharmacogenomics be cost-effective? An analysis of genotype-individualized therapy for children with acute lymphoblastic leukemia. Blood. 2003;102(11).
Ford L, Kampanis P, Berg J. Thiopurine S-methyltransferase genotype-phenotype concordance: used as a quality assurance tool to help control the phenotype assay. Annals of Clinical Biochemistry. 2009;46(Pt 2):152-4. [pmid: 19164342].
Formea CM, Myers-Huentelman H, Wu R, et al. Thiopurine S-methyltransferase genotype predicts azathioprine-induced myelotoxicity in kidney transplant recipients. American Journal of Transplantation. 2004;4(11):1810-7. [pmid: 15476481].
Gisbert JP, Gomollon F, Cara C, et al. Thiopurine methyltransferase (TPMT) activity and inflammatory bowel disease. a study on 7,046 Spanish patients. Gastroenterology. 2005;128.
Gu LJ, Ye QD, Liang AB, et al. Thiopurine methyltransferase (TPMT) activity and its relation to thioguanine nucleotide level in Chinese children with acute lymphoblastic leukemia. Blood. 2001;98.
Gummert J, Schuetz E, Oellerich M, et al. Thiopurine methyltransferase-deficiency, a risk for azathioprine therapy after transplantation?. International Congress Series; Thoracic organ transplantation: Routine as a challenge. 1994:281-5.
Gummert JF, Schutz E, Oellerich M, et al. Monitoring of TPMT in heart transplant recipients under immunosuppressive therapy with azathioprine. Artificial Organs. 1995;19(9):918-20. [pmid: 8687298].
Hawwa AF, Collier PS, Millership JS, et al. Population pharmacokinetic and pharmacogenetic analysis of 6-mercaptopurine in paediatric patients with acute lymphoblastic leukaemia. British Journal of Clinical Pharmacology. 2008;66(6):826-37. [pmid: 18823306].
Hawwa AF, Millership JS, Collier PS, et al. Pharmacogenomic studies of the anticancer and immunosuppressive thiopurines mercaptopurine and azathioprine. British Journal of Clinical Pharmacology. 2008;66(4):517-28. [pmid: 18662289].
Hindorf U, Almer S, Peterson C. Thiopurine methyltransferase and the metabolism of thiopurine drugs in a large Swedish population. Gastroenterology. 2004;126.
Hogarth L, Coulthard S, Hall A, et al. The effect of thiopurine methyltransferase on the cytotoxic action of thiopurine drugs. Leukemia (Basingstoke). 2003;17(3).
Hogarth L, Coulthard S, Skitt L, et al. The effect of thiopurine methyltransferase on the cytotoxic action of thiopurine drugs. British Journal of Haematology. 2003;121.
Hogarth L, Little M, Minto L, et al. High thiopurine methyltransferase expression confers different levels of resistance with 6-thioguanine compared to 6-mercaptopurine. Leukemia (Basingstoke). 2001;15(3).
Hogarth L, Little M, Minto L, et al. In vitro evidence for differences in 6-mercaptopurine versus 6-thioguanine metabolism depending on TPMT status. British Journal of Cancer. 2001;85.
Hon YY, Fessing MY, Pui CH, et al. Polymorphism of the thiopurine S-methyltransferase gene in African-Americans. Human Molecular Genetics. 1999;8(2):371-6. [pmid: 9931346].
Iven H, Kotalczyk A, Gutsche S. Thiopurine S-methyltransferase activity (TPMT) is modulated by disease. Naunyn-Schmiedeberg’s Archives of Pharmacology. 2005;371(Suppl 1).
Kalsi K, Marinaki AM, Yacoub MH, et al. HPLC/tandem ion trap mass detector methods for determination of inosine monophosphate dehydrogenase (IMPDH) and thiopurine methyltransferase (TPMT). Nucleosides, Nucleotides & Nucleic Acids. 2006;25(9–11):1241-4.
Kang HJ, Seo YJ, Lee CJ, et al. Pharmacogenetic study of methotrexate and 6-mercaptopurine related genes in Korean pediatric patients with acute lymphoblastic leukemia. Blood. 2007;110.
Karas-Kuzelicki N, Jazbec J, Milek M, et al. Heterozygosity at the TPMT gene locus, augmented by mutated MTHFR gene, predisposes to 6-MP related toxicities in childhood ALL patients. Leukemia. 2009;23(5):971-4. [pmid: 18987660].
Keuzenkamp-Jansen CW, Leegwater PA, De Abreu RA, et al. Thiopurine methyltransferase: a review and a clinical pilot study. [Review] [53 refs]. Journal of Chromatography B: Biomedical Applications. 1996;678(1):15-22.
Kishi S, Cheng C, Pei D, et al. Genetic Polymorphisms and the toxicity of antileukemic agents in children with acute lymphoblastic leukemia. Blood. 2004;104.
Klemetsdal B, Straume B, Lysaa R, et al. Erythrocyte fraction affects red blood cell thiopurine methyltransferase activity. Proceedings of the American Association for Cancer Research Annual Meeting. 1996;37.
Kodish E, Shaw J, Myers C, et al. Adherence to 6MP in Adolescents with ALL: A Multi-Method Study. Blood. 2002;100(11).
Kontorinis N, Agarwal K, Gondolesi G, et al. Diagnosis of 6 mercaptopurine hepatotoxicity post liver transplantation utilizing metabolite assays. American Journal of Transplantation. 2004;4(9):1539-42. [pmid: 15307844].
Kroeplin T, Weyer N, Fricke L, et al. Influence of thiopurine S-methyltransferase activity and renal function on azathioprine metabolites in patients after kidney transplantation. Naunyn-Schmiedeberg’s Archives of Pharmacology. 1998;357(4 Suppl).
Kubota T, Nishida A, Takeuchi K, et al. Frequency distribution of thiopurine S-methyltransferase activity in red blood cells of a healthy Japanese population. Therapeutic Drug Monitoring. 2004;26(3):319-21. [pmid: 15167635].
Kurzawski M, Dziewanowski K, Gawronska-Szklarz B, et al. The impact of thiopurine s-methyltransferase polymorphism on azathioprine-induced myelotoxicity in renal transplant recipients. Therapeutic Drug Monitoring. 2005;27(4):435-41. [pmid: 16044099].
Kurzawski M, Dziewanowski K, Lener A, et al. TPMT but not ITPA gene polymorphism influences the risk of azathioprine intolerance in renal transplant recipients. European Journal of Clinical Pharmacology. 2009;65(5):533-40. [pmid: 19229528].
Kuzelicki N, Jazbec J, Rascan I. TPMT deficient alleles correlate with higher incidence of 6-MP toxic effects in children with ALL. FEBS Journal. 2007;274.
Lamothe S, Sinnett D, Moghrabi A, et al. Influence of thiopurine methyltransferase (TPMT) and methylenetetrahydrofolate reductase (MTHFR) genotypes on 6-mercaptopurine (6-MP) metabolites in children with ALL. Blood. 2001;98.
Larovere LE, de Kremer RD, Lambooy LH, et al. Genetic polymorphism of thiopurine S-methyltransferase in Argentina. Annals of Clinical Biochemistry. 2003;40(Pt 4):388-93. [pmid: 12880540].
Lennard L, Cartwright C, Wade R, et al. Thioguanine versus mercaptopurine in ALL97: thiopurine metabolism and treatment outcome. British Journal of Haematology. 2008;141(Suppl 1):32-3. [pmid: 18324963].
Lennard L, Gibson B, Nicole T, et al. Dosage requirements for 6-mercaptopurine chemotherapy in the thiopurine methyltransferase deficient child. British Journal of Clinical Pharmacology. 1994;37(1).
Lennard L, Gibson BE, Nicole T, et al. Congenital thiopurine methyltransferase deficiency and 6-mercaptopurine toxicity during treatment for acute lymphoblastic leukaemia. Archives of Disease in Childhood. 1993;69(5):577-9. [pmid: 8257179].
Lennard L, Lilleyman JS, Van LJ, et al. Genetic variation in response to 6-mercaptopurine for childhood acute lymphoblastic leukaemia. Lancet. 1990;336(8709):225-9. [pmid: 1973780].
Lennard L, Richards S, Cartwright CS, et al. The thiopurine methyltransferase genetic polymorphism is associated with thioguanine-related veno-occlusive disease of the liver in children with acute lymphoblastic leukemia. Clinical Pharmacology & Therapeutics. 2006;80(4):375-83. [pmid: 17015055].
Lennard L, Van Loon JA, Lilleyman JS, et al. Thiopurine pharmacogenetics in leukemia: correlation of erythrocyte thiopurine methyltransferase activity and 6-thioguanine nucleotide concentrations. Clinical Pharmacology & Therapeutics. 1987;41(1):18-25. [pmid: 3467886].
Lennard L, Van LJ, Lilleyman J, et al. Thiopurine Pharmacogenetics Correlation of Thiopurine Methyltransferase Activity and 6 Thioguanine Nucleotide Levels. Clinical Pharmacology and Therapeutics. 1986;39(2).
Lennard L, Welch J, Lilleyman JS. Intracellular metabolites of mercaptopurine in children with lymphoblastic leukaemia: a possible indicator of non-compliance?. British Journal of Cancer. 1995;72(4):1004-6. [pmid: 7547211].
Lennard L, Welch JC, Lilleyman JS. Thiopurine drugs in the treatment of childhood leukaemia: the influence of inherited thiopurine methyltransferase activity on drug metabolism and cytotoxicity. British Journal of Clinical Pharmacology. 1997;44(5):455-61. [pmid: 9384462].
Lewing K, Gaedigk A, Woods G, et al. Tolerance of thiopurine therapy in patients with intermediate thiopurine S-methyl transferase (TPMT) activity. Clinical Pharmacology and Therapeutics. 1999;65(2).
Loennechen T, Yates CR, Fessing MY, et al. Isolation of a human thiopurine S-methyltransferase (TPMT) complementary DNA with a single nucleotide transition A719G (TPMT*3C) and its association with loss of TPMT protein and catalytic activity in humans. Clinical Pharmacology & Therapeutics. 1998;64(1):46-51. [pmid: 9695718].
Lowry J, Gaedigk A, Reed L, et al. Variability in thiopurine methyltransferase (TPMT) and outcome in pediatric renal transplant patients. Clinical Pharmacology & Therapeutics. 2003;73(2).
McLeod HL, Coulthard S, Thomas AE, et al. Analysis of thiopurine methyltransferase variant alleles in childhood acute lymphoblastic leukaemia. British Journal of Haematology. 1999;105(3):696-700. [pmid: 10354134].
McLeod HL, Krynetski EY, Wilimas JA, et al. Higher activity of polymorphic thiopurine S-methyltransferase in erythrocytes from neonates compared to adults. Pharmacogenetics. 1995;5(5):281-6. [pmid: 8563768].
McLeod HL, Lin JS, Scott EP, et al. Thiopurine methyltransferase activity in American white subjects and black subjects. Clinical Pharmacology & Therapeutics. 1994;55(1):15-20. [pmid: 8299312].
McLeod HL, Pritchard SC, Githang’a J, et al. Ethnic differences in thiopurine methyltransferase pharmacogenetics: evidence for allele specificity in Caucasian and Kenyan individuals. Pharmacogenetics. 1999;9(6):773-6. [pmid: 10634140].
McLeod HL, Relling MV, Liu Q, et al. Polymorphic thiopurine methyltransferase in erythrocytes is indicative of activity in leukemic blasts from children with acute lymphoblastic leukemia. Blood. 1995;85(7):1897-902. [pmid: 7703493].
Milek M, Jaksic Z, Lukac BJ, et al. Thiopurine S-methyltransferase pharmacogenetics: Genotype to phenotype correlation in the Slovenian population. European Journal of Pharmaceutical Sciences. 2005;25(Suppl1):S157-S159.
Mircheva J, Legendre C, Soria-Royer C, et al. Monitoring of azathioprine-induced immunosuppression with thiopurine methyltransferase activity in kidney transplant recipients.[see comment]. Transplantation. 1995;60(7):639-42. [pmid: 7570968].
Moloney FJ, Dicker P, Conlon PJ, et al. The frequency and significance of thiopurine S-methyltransferase gene polymorphisms in azathioprine-treated renal transplant recipients. British Journal of Dermatology. 2006;154(6):1199-200. [pmid: 16704656].
Mousson C, Escousse A, Mounie J, et al. Effects of immunosuppressive drugs (therapy with azathioprine) on TPMT activity in erythrocytes from renal transplant patients and insufficient renal subjects. Methods and Findings in Experimental and Clinical Pharmacology. 1996;18.
Murphy LA, Atherton DJ. Azathioprine as a treatment for severe atopic eczema in children with a partial thiopurine methyl transferase (TPMT) deficiency. Pediatric Dermatology. 2003;20(6):531-4. [pmid: 14651577].
Nygaard U, Schmiegelow K. Dose reduction of coadministered 6-mercaptopurine decreases myelotoxicity following high-dose methotrexate in childhood leukemia. Leukemia. 2003;17(7):1344-8. [pmid: 12835723].
Nygaard U, Toft N, Schmiegelow K. Methylated metabolites of 6-mercaptopurine are associated with hepatotoxicity. Clinical Pharmacology & Therapeutics. 2004;75(4):274-81. [pmid: 15060506].
Otterness D, Szumlanski C, Wood T, et al. Thiopurine methyltransferase (TPMT) pharmacogenetics: Polymorphism characterization. Clinical Pharmacology and Therapeutics. 1997;61(2).
Pacifici GM, Romiti P, Giuliani L, et al. Thiopurine methyltransferase in humans: development and tissue distribution. Developmental Pharmacology & Therapeutics. 1991;17(1–2):16-23. [pmid: 1811918].
Pandya B, Thomson W, Poulton K, et al. Azathioprine toxicity and thiopurine methyltransferase genotype in renal transplant patients. Transplantation Proceedings. 2002;34(5):1642-5. [pmid: 12176518].
Park-Hah JO, Klemetsdal B, Lysaa R, et al. Thiopurine methyltransferase activity in a Korean population sample of children. Clinical Pharmacology & Therapeutics. 1996;60(1):68-74. [pmid: 8689814].
Pazmino PA, Sladek SL, Weinshilboum RM. Thiol S-methylation in uremia: erythrocyte enzyme activities and plasma inhibitors. Clinical Pharmacology & Therapeutics. 1980;28(3):356-67. [pmid: 7408396].
Pettersson B, Albertioni F, Soderhall S, et al. Thiopurine S-methyltransferase activity in an adult Swedish population and in children with acute lymphoblastic leukemia on remission maintenance therapy. European Journal of Clinical Pharmacology. 1997;52.
Pettersson B, Almer S, Albertioni F, et al. Differences between children and adults in thiopurine methyltransferase activity and metabolite formation during thiopurine therapy: possible role of concomitant methotrexate. Therapeutic Drug Monitoring. 2002;24(3):351-8. [pmid: 12021625].
Pui C, Relling MV, Sandlund J, et al. Total therapy study XV for newly diagnosed childhood acute lymphoblastic leukemia: Study design and preliminary results. Annals of Hematology. 2006;85(Suppl 1):88-91.
Rabello C, Hall A. Wide inter and intra-patient variability of erythrocyte thioguanine nucleotides levels and thiopurine methyltransferase activity in childhood leukaemia. Proceedings of the American Association for Cancer Research Annual Meeting. 1996;37.
Reis M, Santoro A, Suarez-Kurtz G. Thiopurine methyltransferase phenotypes and genotypes in Brazilians. Pharmacogenetics. 2003;13(6):371-3. [pmid: 12777968].
Relling MV, Hancock ML, Boyett JM, et al. Prognostic importance of 6-mercaptopurine dose intensity in acute lymphoblastic leukemia. Blood. 1999;93(9):2817-23. [pmid: 10216075].
Relling MV, Hancock ML, Rivera GK, et al. Mercaptopurine therapy intolerance and heterozygosity at the thiopurine S-methyltransferase gene locus.[see comment]. Journal of the National Cancer Institute. 1999;91(23):2001-8. [pmid: 10580024].
Reuther LO, Sonne J, Larsen N, et al. Thiopurine methyltransferase genotype distribution in patients with Crohn’s disease. Alimentary Pharmacology & Therapeutics. 2003;17(1):65-8. [pmid: 12492733].
Reuther LO, Vainer B, Sonne J, et al. Thiopurine methyltransferase (TPMT) genotype distribution in azathioprine-tolerant and -intolerant patients with various disorders. The impact of TPMT genotyping in predicting toxicity. European Journal of Clinical Pharmacology. 2004;59(11):797-801. [pmid: 14634700].
Roblin X, Serre-Debeauvais F, Heluwaert F, et al. Early and transient increase of 6-TGN after infliximab infusion in patients with Crohns disease under azathioprine: Possible mechanisms. Gastroenterology. 2004;126.
Rossi AM, Bianchi M, Guarnieri C, et al. Genotype-phenotype correlation for thiopurine S-methyltransferase in healthy Italian subjects. European Journal of Clinical Pharmacology. 2001;57(1):51-4. [pmid: 11372592].
Rossino R, Vincis C, Alves S, et al. Frequency of the thiopurine S-methyltransferase alleles in the ancient genetic population isolate of Sardinia. Journal of Clinical Pharmacy & Therapeutics. 2006;31(3):283-7. [pmid: 16789994].
Samochatova EV, Karachunsky AI, Myakova NV, et al. Activity of thiopurine methyltransferase in children with acute lymphoblastic leukemia. Gematologiya i Transfuziologiya. 2002;47(6):17-20.
Samochatova EV, Chupova NV, Rudneva A, et al. TPMT genetic variations in populations of the Russian Federation. Pediatric Blood & Cancer. 2009;52(2):203-8. [pmid: 19034904].
Samochatova EV, Chupova NV, Roudneva AE, et al. Genetic polymorphism of thiopurine S-methyltransferase in the Russian population. Blood. 2005;106.
Sasaki T, Goto E, Konno Y, et al. Three novel single nucleotide polymorphisms of the human thiopurine S-methyltransferase gene in Japanese individuals. Drug Metabolism & Pharmacokinetics. 2006;21(4):332-6. [pmid: 16946561].
Savage C, Chew T, Lilleyman J, et al. Thiopurine methyltransferase in childhood leukaemia: Variation in enzyme activity at disease diagnosis and during chemotherapy. British Journal of Clinical Pharmacology. 2002;53(4).
Schaeffeler E, Fischer C, Brockmeier D, et al. Comprehensive analysis of thiopurine S-methyltransferase phenotype-genotype correlation in a large population of German-Caucasians and identification of novel TPMT variants.[see comment]. Pharmacogenetics. 2004;14(7):407-17. [pmid: 15226673].
Schmiegelow K, Bjork O, Glomstein A, et al. Intensification of mercaptopurine/methotrexate maintenance chemotherapy may increase the risk of relapse for some children with acute lymphoblastic leukemia. Journal of Clinical Oncology. 2003;21(7):1332-9. [pmid: 12663723].
Schmiegelow K, Forestier E, Kristinsson J, et al. Thiopurine methyltransferase activity is related to the risk of relapse of childhood acute lymphoblastic leukemia: results from the NOPHO ALL-92 study. Leukemia. 2009;23(3):557-64. [pmid: 18987654].
Schmiegelow K, Al-Modhawi I, Berendtz M, et al. Risk of second malignant neoplasm is related to TPMT activity and duration of MTX/6MP maintenance therapy of ALL. Blood. 2006;108.
Schmiegelow K, Bjork O, Glomstein A, et al. Intensification of 6-Mercaptopurine/Methotrexate Maintenance Chemotherapy May Increase the Risk of Relapse for Some Children with ALL. Blood. 2002;100(11).
Schmiegelow K, Nygaard U. Methylated metabolites of 6-mercaptopurine are associated with hepatotoxicity in childhood leukemia. Blood. 2003;102(11).
Schutz E, Gummert J, Armstrong VW, et al. Azathioprine pharmacogenetics: the relationship between 6-thioguanine nucleotides and thiopurine methyltransferase in patients after heart and kidney transplantation. European Journal of Clinical Chemistry & Clinical Biochemistry. 1996;34(3):199-205. [pmid: 8721407].
Sebbag L, Boucher P, Davelu P, et al. Thiopurine S-methyltransferase gene polymorphism is predictive of azathioprine-induced myelosuppression in heart transplant recipients. Transplantation. 2000;69(7):1524-7. [pmid: 10798786].
Seki T, Tanaka T, Nakamura Y. Genomic structure and multiple single-nucleotide polymorphisms (SNPs) of the thiopurine S-methyltransferase (TPMT) gene. Journal of Human Genetics. 2000;45(5):299-302. [pmid: 11043513].
Serre-Debeauvais F, Bayle F, Bosson J, et al. Thiopurine methyl transferase (TPMT) activity: Influence on azathioprine therapy in renal transplantation. Fundamental and Clinical Pharmacology. 1996;10(1).
Silva MR, de Oliveira BM, Viana MB, et al. Thiopurine S-methyltransferase (TPMT) gene polymorphism in brazilian children with acute lymphoblastic leukemia: association with clinical and laboratory data. Therapeutic Drug Monitoring. 2008;30(6):700-4. [pmid: 19057372].
Smart C, Jones C, Nwadike N, et al. Thiopurine Methyltransferase Tpmt Activity in A Haitian Sample Population Clinical Pharmacology and Therapeutics. 1991;49(2).
Smart CA, Jones CD, Dorvil M, et al. Thiopurine methyltransferase activity in a Haitian population. Journal of Pharmaceutical Medicine. 1995;5(3–4):169-76.
Somer M, Pesonen U, Kallio J, et al. Genetic variation of thiopurine S-methyltransferase activity in a Finnish population. Human and Experimental Toxicology. 1997;16(10):624.
Song DK, Zhao J, Zhang LR. TPMT genotype and its clinical implication in renal transplant recipients with azathioprine treatment. Journal of Clinical Pharmacy & Therapeutics. 2006;31(6):627-35. [pmid: 17176368].
Soria-Royer C, Legendre C, Mircheva J, et al. Thiopurine-methyl-transferase activity to assess azathioprine myelotoxicity in renal transplant recipients. Lancet. 1993;341(8860):1593-4. [pmid: 8099662].
Sproul AM, Davidson EA, Tariq N, et al. Thiopurine methyltransferase gene polymorphisms in individuals of Pakistani origin in Scotland. Blood. 1999;94.
Srimartpirom S, Tassaneeyakul W, Kukongviriyapan V, et al. Thiopurine S-methyltransferase genetic polymorphism in the Thai population. British Journal of Clinical Pharmacology. 2004;58(1):66-70. [pmid: 15206995].
Stanulla M, Schaeffeler E, Flohr T, et al. Thiopurine methyltransferase (TPMT) genotype and early treatment response to mercaptopurine in childhood acute lymphoblastic leukemia. JAMA. 2005;293(12):1485-9. [pmid: 15784872].
Stanulla M, Schaeffeler E, Moericke A, et al. Thiopurine methyltransferase genotype is not a risk factor for secondary malignant neoplasias after treatment for childhood acute lymphoblastic leukemia on Berlin-Frankfurt-Muenster protocols. Blood. 2006;108(11 Part 1):48A-9A.
Stanulla M, Schaffeler E, Flohr T, et al. Thiopurine methyltransferase genotype modulates early treatment response to 6-mercaptopurine as measured by minimal residual disease in childhood acute lymphoblastic leukemia. Blood. 2004;104.
Steiner M, Burmeister D, Bastian M, et al. Elevated serum pancreatic enzyme activities in kidney transplant recipients and azathioprine drug therapy: is thiopurine methyltransferase polymorphism one missing link?. Urologia Internationalis. 2002;68(2):135-6. [pmid: 11834908].
Stocco G, Cheok MH, Crews KR, et al. Genetic polymorphism of inosine triphosphate pyrophosphatase is a determinant of mercaptopurine metabolism and toxicity during treatment for acute lymphoblastic leukemia. Clinical Pharmacology & Therapeutics. 2009;85(2):164-72. [pmid: 18685564].
Stocco G, Cheok M, Yang W, et al. Inosine-triphosphate-pyrophosphatase genotype is a determinant of severe fever with neutropenia following treatment of acute lymphoblastic leukemia with combination chemotherapy that includes mercaptopurine adjusted for thiopurine-S-methyltransferase genotype. Blood. 2007;110.
Taja-Chayeb L, Vidal-Millan S, Gutierrez O, et al. Thiopurine S-methyltransferase gene (TMPT) polymorphisms in a Mexican population of healthy individuals and leukemic patients. Medical Oncology. 2008;25(1):56-62. [pmid: 18188716].
Tamm R, Oselin K, Kallassalu K, et al. Thiopurine S-methyltransferase (TPMT) pharmacogenetics: three new mutations and haplotype analysis in the Estonian population. Clinical Chemistry & Laboratory Medicine. 2008;46(7):974-9. [pmid: 18605963].
Thervet E, Anglicheau D, Toledano N, et al. Long-term results of TMPT activity monitoring in azathioprine-treated renal allograft recipients. Journal of the American Society of Nephrology. 2001;12(1):170-6. [pmid: 11134264].
Toft N, Nygaard U, Gregers J, et al. Genetic analyses of thiopurine methyltransferase polymorphisms in Greenlandic and Danish populations. Acta Paediatrica. 2006;95(12):1665-7. [pmid: 17129980].
Tumer TB, Ulusoy G, Adali O, et al. The low frequency of defective TPMT alleles in Turkish population: a study on pediatric patients with acute lymphoblastic leukemia. American Journal of Hematology. 2007;82(10):906-10. [pmid: 17617792].
Turner TB, Adali O, Ulusoy G, et al. Genetic polymorphisms of thiopurine methyltransferase enzyme in children with acute lympoblastic leukemia in Turkish population: A preliminary study on TPMT*3A and TPMT*3C alleles. Drug Metabolism Reviews. 2006;38.
van den Akker-van Marle ME, Gurwitz D, Detmar SB, et al. Cost-effectiveness of pharmacogenomics in clinical practice: a case study of thiopurine methyltransferase genotyping in acute lymphoblastic leukemia in Europe. Pharmacogenomics. 2006;7(5):783-92. [pmid: 16886902].
Van Loon JA, Weinshilboum RM. Human lymphocyte thiopurine methyltransferase pharmacogenetics: effect of phenotype on 6-mercaptopurine-induced inhibition of mitogen stimulation. Journal of Pharmacology & Experimental Therapeutics. 1987;242(1):21-6. [pmid: 3612526].
Vora AJ, Mitchell C, Kinsey S, et al. Thioguanine-Related Veno-Occlusive Disease (VOD) of the Liver in Children with Acute Lymphoblastic Leukaemia (ALL): Report from United Kingdom Medical Research Council (UK MRC) Trial ALL97. Blood. 2002;100(11).
Vuchetich JP, Weinshilboum RM, Price RA. Segregation analysis of human red blood cell thiopurine methyltransferase activity. Genetic Epidemiology. 1995;12(1):1-11. [pmid: 7713396].
Wei H, Zhou S, Li C, et al. Phenotyping and genotyping studies of thiopurine S-methyltransferase in Kazaks. Pharmaceutical Research. 2005;22(10):1762-6. [pmid: 16180135].
Weinshilboum R, Sladek S. Pharmaco Genetics of Thio Purines Inherited Variations of Thio Purine Methyl Transferase Activity. Clinical Pharmacology and Therapeutics. 1980;27(2).
Weinshilboum RM, Sladek SL. Mercaptopurine pharmacogenetics: Inherited lack of thiopurine methyltransferase activity. Clinical Research. 1979;27(4):631A.
Weyer N, Kroeplin T, Fricke L, et al. Thiopurine S-methyltransferase activity in uremia and after renal transplantation. Naunyn-Schmiedeberg’s Archives of Pharmacology. 1998;357(4 SUPPL).
Weyer N, Kroplin T, Fricke L, et al. Human thiopurine S-methyltransferase activity in uremia and after renal transplantation. European Journal of Clinical Pharmacology. 2001;57(2):129-36. [pmid: 11417444].
Woodson LC, Dunnette JH, Weinshilboum RM. Biochemical genetics of human erythrocyte (RBC) thiopurine methyltransferase (TPMT): Correlation of immunoreactive protein with enzyme activity. Pharmacologist. 1981;23(3).
Wusk B, Kullak-Ublick GA, Rammert C, et al. Thiopurine S-methyltransferase polymorphisms: efficient screening method for patients considering taking thiopurine drugs. European Journal of Clinical Pharmacology. 2004;60(1):5-10. [pmid: 14985890].
Xin HW, Xiong H, Wu XC, et al. Relationships between thiopurine S-methyltransferase polymorphism and azathioprine-related adverse drug reactions in Chinese renal transplant recipients. European Journal of Clinical Pharmacology. 2009;65(3):249-55. [pmid: 19048245].
Yates CR, Krynetski E, Tai HL, et al. TPMT*3 is the most prevalent mutant allele associated with thiopurine S-methyltransferase (TPMT) deficiency in Caucasians. Clinical Pharmacology and Therapeutics. 1996;59(2).
Ye Q, Zhao J, Liang A, et al. Hereditary polymorphism of thiopurine S-methyltransferase activity in a Chinese Han population in Shanghai area. Blood. 1999;94.
Zhang JP, Guan YY, Wu JH, et al. Phenotyping and genotyping study of thiopurine S-methyltransferase in healthy Chinese children: a comparison of Han and Yao ethnic groups. British Journal of Clinical Pharmacology. 2004;58(2):163-8. [pmid: 15255798].
Zhang JP, Guan YY, Xu AL, et al. Gene mutation of thiopurine S-methyltransferase in Uygur Chinese. European Journal of Clinical Pharmacology. 2004;60(1):1-3. [pmid: 14985891].
Zhang JP, Zhou SF, Chen X, et al. Determination of intra-ethnic differences in the polymorphisms of thiopurine S-methyltransferase in Chinese. Clinica Chimica Acta. 2006;365(1–2):337-41.
Zhang L, Zhang W, Yin Z, et al. Genetic polymorphisms of drug-metabolizing enzymes CYP2C19, NAT2, and TPMT in a Han Chinese population from Henan area. Zhongguo Xinyao yu Linchuang Zazhi. 2006;25(8):561-6.
Zhang LR. Thiopurine S-methyltransferase genotype predicts adverse drug reactions to thiopurine drugs in renal transplant recipients. Acta Pharmacologica Sinica. 2006;27.

### Exclude on language (other than English), n = 2

Chalupna P, Lukas M, Kumsta M, et al. Effect of the activity of thiopurine methyltransfrase on the results of long-term immunosuppressive therapy with azathioprin (6-mercaptopurine) in patients with inflammatory bowel diseases. [Czech]. Ceska a Slovenska Gastroenterologie a Hepatologie. 2002;56(6):208-13.
Chupova NV, Samochatova EV, Rudneva A, et al. Genetic polymorphism of thiopurine-S-methyltransferase and treatment of childhood acute lymphoblastic leukemia. Gematologiya i Transfuziologiya. 2005;50(6):3-9.

### Exclude on non-availability of abstracts and full text, n = 11

Chew C, Evans C, Curry G, et al. Audit of long term azathioprine use in inflammatory bowel disease. Gastroenterology. 2000;118.
Colombel J, Touze I, Catala P, et al. Genotypic analysis of the thiopurine s-methyltransferase (TPMT) gene in patients with Crohn’s Disease and severe myelosuppression during azathioprine therapy. Gastroenterology. 1999;116.
Dubinsky M, Lamothe S, Yang H, et al. Optimizing and individualizing 6-MP therapy in IBD: The role of 6-MP metabolite levels and TPMT genotyping. Gastroenterology. 1999;116.
Hassan C, Duley J, Ansari A, et al. Thiopurine S-methyltransferase activity in inflammatory bowel disease: A retrospective study. Gastroenterology. 1999;116.
Kaskas BA, SchSffeler E, Lang T, et al. Gastrointestinal side effects of azathioprine in patients with inflammatory bowel disease are not related to thiopurine methyltransferase polymorphism. Gastroenterology. 2000;118.
Khan ZH, Marinaki A, Bakre MS, et al. Thiopurine methyltransferase activity and genetic polymorphism among British Asian patients with inflammatory bowel disease. Gastroenterology. 2000;118.
Oh K, Anis A, Bae S. Pharmacoeconomic analysis of thiopurine methyltransferase polymorphism screening by polymerase chain reaction in the treatment with azathioprine in Korea. Annals of the Rheumatic Diseases. 2003;62.
Proujansky R, Maxwell M, Johnston J, et al. Molecular genotyping predicts complications of 6-mercaptopurine therapy in childhood IBD. Gastroenterology. 1999;116.
Schwab M, Schaeffeler E, Marx C, et al. Shortcoming in the diagnosis of TPMT deficiency in a patient with Crohn’s disease using phenotyping only. Gastroenterology. 2001;121(2):498-9. [pmid: 11487563].
Tani C, Mosca M, Gori G, et al. Azathioprine pharmacogenetic in a cohort of patients with autoimmune rheumatic disease. Annals of the Rheumatic Diseases. 2007;66(Suppl 2):252-3.
Watanabe K, Simmons JD, Orchard TR, et al. Allelic variants of thiopurine methyl transferase are associated with Azathioprine induced leukopaenia. Gastroenterology. 2000;118.

### Exclude on another reason, n = 118

Aithal GP, Hoffman BJ. Steering azathioprine safely: Lessons from pharmacogenetics. American Journal of Gastroenterology. 2001;96(11):3202-3. [pmid: 11721776].
Almer SH, Hjortswang H, Peterson C, et al. 6-thioguanine therapy in Crohn’s disease - A Swedish experience. Gastroenterology. 2007;132.
Ansari A, Aslam Z, De SA, et al. Influence of xanthine oxidase on thiopurine metabolism in Crohn’s disease. Alimentary Pharmacology & Therapeutics. 2008;28(6):749-57. [pmid: 18557988].
Ansari A, Elliott T, Baburajan B, et al. Long-term outcome of using allopurinol co-therapy as a strategy for overcoming thiopurine hepatotoxicity in treating inflammatory bowel disease. Alimentary Pharmacology & Therapeutics. 2008;28(6):734-41. [pmid: 19145729].
Ansari A, Escudier M, Marinaki A, et al. Treatment of zero and intermediate TPMT patients with a tailored dose of azathioprine. Gut. 2003;52.
Ansari A, Marinaki A, Arenas M, et al. Polymorphism in the MTHFR gene affects TPMT activity. Gut. 2003;52.
Ansari AR, Escudier M, Shobowala-Barkre EM, et al. Responses to low dose azathioprine in patients withheterozygous thiopurine methyl transferase deficiency. Gastroenterology. 2001;120.
Ansari AR, Yang S, Arenas M, et al. Lack of Association Between Vntr’S and Tpmt Induction in Response to Azathioprine. Digestive Disease Week Abstracts and Itinerary Planner. 2003.
Arenas M, Duley JA, Ansari A, et al. Genetic determinants of the pre- and post-azathioprine therapy thiopurine methyltransferase activity phenotype. Nucleosides, Nucleotides & Nucleic Acids. 10. 2004;23(8–9):1403-5.
Arenas M, Marinaki A, Lewis C, et al. Genetic determinants of the thiopurine methyltransferase intermediate activity phenotype. Gut. 2003;52.
Ban H, Andoh A, Tanaka A, et al. Analysis of thiopurine S-methyltransferase genotypes in Japanese patients with inflammatory bowel disease. Internal Medicine. 2008;47(19):1645-8. [pmid: 18827410].
Benenson E, Fries JW, Heilig B, et al. High-dose azathioprine pulse therapy as a new treatment option in patients with active Wegener’s granulomatosis and lupus nephritis refractory or intolerant to cyclophosphamide. Clinical Rheumatology. 06. 2005;24(3):251-7. [pmid: 15940558].
Bierau J, Bakker JA, Lindhout M, et al. Determination of ITPase activity in erythrocyte lysates obtained for determination of TPMT activity. Nucleosides, Nucleotides & Nucleic Acids. 2006;25(9–11):1129-32.
Bloomfeld RS, Bickston SJ, Levine ME, et al. Thiopurine methyltransferase activity is correlated with azathioprine metabolite levels in patients with inflammatory bowel disease in clinical gastroenterology practice. Journal of Applied Research. 2006;6(4):282-7.
Bloomfeld RS, Bickston SJ, Levine ME, et al. Thiopurine methyltransferase activity is correlated with azathioprine metabolite levels in inflammatory bowel disease patients in clinical gastroenterology practice. American Journal of Gastroenterology. 2004;99.
Bokemeyer B, Roggel C, Hartmann P, et al. Compliance with azathioprine therapy in outpatients with IBD: correlation to TDM. Gastroenterology. 2005;128.
Cao Q, Zhu Q, Shang Y, et al. Thiopurine methyltransferase gene polymorphisms in Chinese patients with inflammatory bowel disease. Digestion. 2009;79(1):58-63. [pmid: 19252404].
Cara C, Gomollon F, Gisbert J, et al. Thio purine methyl transferase (TPMT) phenotype in a large group of inflammatory bowel disease patients and control population in Spain. Gastroenterology. 2002;122(4 Suppl 1):A-220.
Cheon JH, Kim JH, Kim BY, et al. Allele frequency of thiopurine methyltransferase and inosine triphosphate pyrophosphatase gene polymorphisms in korean patients with inflammatory bowel diseases. Hepato-Gastroenterology. 2009;56(90):421-3. [pmid: 19579612].
Colombel JF, Ferrari N, Debuysere H, et al. Genotypic analysis of thiopurine S-methyltransferase in patients with Crohn’s disease and severe myelosuppression during azathioprine therapy. Gastroenterology. 06. 2000;118(6):1025-30. [pmid: 10833476].
Comer M, James I, D’Cruz D, et al. A novel non-radionuclide assay for erythrocyte thiopurine methyltransferase (TPMT) activity; potential for clinical use in rheumatology. Arthritis and Rheumatism. 1998;41.
Cooley R, McWhinny B, Templeton D, et al. Prospective analysis of purine metabolites and their relationships with markers of disease activity and with smoking in an Australian Crohn’s disease population. Gastroenterology. 2005;128.
Corominas H, Domenech M, Gonzalez D, et al. Allelic variants of the thiopurine S-methyltransferase deficiency in patients with ulcerative colitis and in healthy controls. American Journal of Gastroenterology. 09. 2000;95(9):2313-7. [pmid: 11007234].
Cuffari C, Theoret Y, Latour S, et al. 6-Mercaptopurine metabolism in Crohn’s disease: correlation with efficacy and toxicity.[see comment][erratum appears in Gut. 1998 Aug;43(2):301; PMID: 10189865]. Gut. 09. 1996;39(3):401-6. [pmid: 8949645].
Cuffari C, Dasspoulos T, Turnbaugh L, et al. Thiopurine methyltransferase (TPMT) activity influences clinical response to maintenance azathioprine therapy in patients with IBD. Gastroenterology. 2002;122(4 Suppl 1):A-221.
Cuffari C, Maqbool A, Jones L, et al. Thiopurine methyl-transferase activity influences clinical response to azathioprine therapy in patients with IBD. Gastroenterology. 2001;120.
Daniel F, Cadranel JF, Seksik P, et al. Azathioprine-induced nodular regenerative hyperplasia (NRH) of the liver in IBD patients. Gastroenterology. 2004;126.
Daperno M, Sostegni R, Canaparo R, et al. Prospective study of the effects of concomitant medications on thiopurine metabolism in inflammatory bowel disease. Alimentary Pharmacology and Therapeutics. 2009;30(8):843-853. Date of Publication: October 2009. [pmid: 19650826]. 2009;(8):843-53.
De Abreu R, Keizer-Garritsen J, Brouwer C, et al. Hematological toxicity during thiopurine treatment: Association with thiopurine enzyme deficiency. Journal of Inherited Metabolic Disease. 2000;23.
de Boer NK, Derijks LJ, Keizer-Garritsen JJ, et al. Extended thiopurine metabolite assessment during 6-thioguanine therapy for immunomodulation in Crohn’s disease. Journal of Clinical Pharmacology. 02. 2007;47(2):187-91. [pmid: 17244769].
de Boer NK, van Asseldonk DP, van Bodegraven AA. On the malignant potential of thiopurine therapy.[comment]. Blood. 06. 11. 2009;113(24):6258-9. [pmid: 19520817].
Deibert P, Dilger K, Hofmann U, et al. High Variation of 6-Thioguanine Absorption in Patients with Chronic Active Crohn’S Disease. Digestive Disease Week Abstracts and Itinerary Planner 2003. 2003.
Derijks LJ, Gilissen LP, Engels LG, et al. Pharmacokinetics of 6-thioguanine in patients with inflammatory bowel disease. Therapeutic Drug Monitoring. 02. 2006;28(1):45-50. [pmid: 16418693].
Dubinsky M, Hassard P, Kam L, et al. An open label pilot study evaluating the safety, tolerance and efficacy of thioguanine (6-TG) as an alternate therapy in patients failing 6-mercaptopurine (6-MP). American Journal of Gastroenterology. 2000;95(9).
Dubinsky M, Reyes E, Ofman J, et al. Cost-effectiveness analysis of thiopurine methyltransferase (TPMT) screening and metabolite monitoring (MM) in the management of azathioprine (AZA): Treated Crohn’s disease (CD) patients. American Journal of Gastroenterology. 2003;98.
Dubinsky MC, Hassard PV, Abreu MT, et al. Thioguanine (6-TG): A therapeutic alternative in a subgroup of IBD patients failing 6-mercaptopurine (6-MP). Gastroenterology. 2000;118.
Ford L, Kampanis P, Berg J. Thiopurine S-methyltransferase genotype-phenotype concordance: used as a quality assurance tool to help control the phenotype assay. Annals of Clinical Biochemistry. 03. 2009;46(Pt 2):152-4. [pmid: 19164342].
Foster EN, Scott BA, Dhawan D, et al. 6-Mercaptopurine metabolite levels in patients with inflammatory bowel disease. Gastroenterology. 2002;122(4 Suppl 1):A-221.
Garat A, Cauffiez C, Renault N, et al. Characterisation of novel defective thiopurine S-methyltransferase allelic variants. Biochemical Pharmacology. 08. 1. 2008;76(3):404-15. [pmid: 18602085].
Gardiner SJ, Gearry RB, Roberts RL, et al. Exposure to thiopurine drugs through breast milk is low based on metabolite concentrations in mother-infant pairs. British Journal of Clinical Pharmacology. 10. 2006;62(4):453-6. [pmid: 16995866].
Gazouli M, Pachoula I, Panayotou I, et al. Thiopurine S-methyltransferase genotype and the use of thiopurines in paediatric inflammatory bowel disease Greek patients. Journal of Clinical Pharmacy and Therapeutics. 2010;35(1):93-97. [pmid: 20175817].
Gearry RB, Barclay ML, Roberts RL, et al. Thiopurine methyltransferase and 6-thioguanine nucleotide measurement: early experience of use in clinical practice. Internal Medicine Journal. 10. 2005;35(10):580-5. [pmid: 16207256].
Gerich M, Quiros J, Marvin JP, et al. Prevalence and clinical characteristics of 6-mercaptopurine rapid metabolizers among adult and pediatric inflammatory bowel disease patients. Gastroenterology. 2007;132.
Gisbert JP, Luna M, Mate J, et al. Choice of azathioprine or 6-mercaptopurine dose based on thiopurine methyltransferase (TPMT) activity to avoid myelosuppression. A prospective study. Hepato-Gastroenterology. 05. 2006;53(69):399-404. [pmid: 16795981].
Gisbert JP, Gomollon F, Cara C, et al. Thiopurine methyltransferase (TPMT) activity in Spain. a study on 14,545 patients. Gastroenterology. 2005;128.
Gisbert JP, Gonzalez-Iama Y, Bermejo F, et al. 6-thioguanine nucleotide (6-Tgn) concentrations and efficacy of azathioprine (AZA) and mercaptopurine (Mp) in inflammatory bowel disease: The Metaza study. Gastroenterology. 2007;132.
Gonzalez-Del AA, Bermudez-Lopez C, Alcantara-Ortigoza MA, et al. Thiopurine S-methyltransferase (TPMT) genetic polymorphisms in Mexican newborns. Journal of Clinical Pharmacy and Therapeutics. 2009;34(6):703-708. [pmid: 20175804].
Gonzalez-Lama Y. Utility of azathioprine metabolites determination during follow up of inflammatory bowel disease patients after steroid treatment withdrawal. Gastroenterology. 2008;134.
Hall AG, Hamilton P, Minto L, et al. The use of denaturing high-pressure liquid chromatography for the detection of mutations in thiopurine methyltransferase. Journal of Biochemical & Biophysical Methods. 01. 30. 2001;47(1–2):65-71. [pmid: 11179762].
Hamdan-Khalil R, Gala JL, Allorge D, et al. Identification and functional analysis of two rare allelic variants of the thiopurine S-methyltransferase gene, TPMT*16 and TPMT*19. Biochemical Pharmacology. 02. 1. 2005;69(3):525-9. [pmid: 15652243].
Hande S, Wilson-Rich N, Bousvaros A, et al. 5-aminosalicylate therapy is associated with higher 6-thioguanine levels in adults and children with inflammatory bowel disease in remission on 6-mercaptopurine or azathioprine. Inflammatory Bowel Diseases. 04. 2006;12(4):251-7. [pmid: 16633046].
Hande S, Wilson-Rich N, Maurer R, et al. 5-aminosalicylates are associated with higher 6-thioguanine levels in stable IBD patients on azathioprine or 6-mercaptopurine. American Journal of Gastroenterology. 2005;100.
Hiratsuka M, Agatsuma Y, Omori F, et al. High throughput detection of drug-metabolizing enzyme polymorphisms by allele-specific fluorogenic 5′ nuclease chain reaction assay. Biological & Pharmaceutical Bulletin. 10. 2000;23(10):1131-5. [pmid: 11041238].
Joy D, MacPherson R, Campbell S, et al. Relationship of thiopurine methyltransferase (TPMT) activity to mean corpuscular volume (MCV) in inflammatory bowel disease (IBD) patients maintained on azathioprine. Gut. 2002;50.
Jung YS, Cheon JH, Park JJ, et al. Correlation of genotypes for thiopurine methyltransferase and inosine triphosphate pyrophosphatase with long-term clinical outcomes in Korean patients with inflammatory bowel diseases during treatment with thiopurine drugs. Journal of Human Genetics. 2010;55(2):121-123. [pmid: 19960028].
Kampa M, Rasouli O, Mitropoulos C, et al. A simple and fast method for genotyping drug metabolizing enzymes CYP2D6, CYP2C19, and TPMT. FEBS Journal. 2006;273.
Kerstens PJ, Stolk JN, Boerbooms AM, et al. Purine enzymes in rheumatoid arthritis: possible association with response to azathioprine. A pilot study. Annals of the Rheumatic Diseases. 09. 1994;53(9):608-11. [pmid: 7979599].
Komiyama T, Yajima T, Kubota R, et al. Lower doses of 6-mercaptopurine/azathioprine bring enough clinical efficacy and therapeutic concentration of erythrocyte 6-mercaptopurine metabolite in Japanese IBD patients. Journal of Crohn’s and Colitis. 2008;2(4):315-21.
Kwan LY, Devlin SM, Mirocha JM, et al. Baseline thiopurine methyltransferase (TPMT) activity combined with 6-thioguanine (6-TGN) metabolite levels predicts clinical response to thiopurines in patients with inflammatory bowel disease. American Journal of Gastroenterology. 2006;101.
Languepin J, Faure C, Munck A, et al. Efficacy, tolerance of azathioprine and pharmacogenetic of thiopurine methyltransferase in pediatric inflammatory bowel disease. JPGN Journal of Pediatric Gastroenterology and Nutrition. 2001;32(3).
Lees C, Maan A, Hansoti B, et al. Tolerability of 6-mercaptopurine in azathioprine intolerant patients with inflammatory bowel disease. Gastroenterology. 2007;132.
Lentz JJ, Barry M, Rose SL. Do IBD patients show the same tri-modal distribution for TPMT enzyme as reported in various ethnic populations. American Journal of Gastroenterology. 2000;95(9).
Liang A, Gu L, Ye H, et al. Report of 2 Unidentified Candidate Single Nucleotide Polymorphisms (SNPs) of Thiopurine Methyltransferase (TPMT) Gene in a Chinese Han Population. Blood. 2002;100(11).
Lindqvist M, Almer S, Peterson C, et al. Real-time RT-PCR methodology for quantification of thiopurine methyltransferase gene expression. European Journal of Clinical Pharmacology. 07. 2003;59(3):207-11. [pmid: 12819840].
Lindqvist M, Haglund S, Almer S, et al. Identification of two novel sequence variants affecting thiopurine methyltransferase enzyme activity. Pharmacogenetics. 04. 2004;14(4):261-5. [pmid: 15083071].
Lindqvist M, Almer S, Haglund S, et al. Identification of two novel sequence variants affecting thiopurine methyltransferase enzyme activity. Clinical and Experimental Pharmacology and Physiology. 2004;31(11).
Loennechen T, Utsi E, Hartz I, et al. Detection of one single mutation predicts thiopurine S-methyltransferase activity in a population of Saami in northern Norway. Clinical Pharmacology & Therapeutics. 08. 2001;70(2):183-8. [pmid: 11503013].
Loo G, Smith JT. Glutathione An Endogenous Substrate for Thiopurine Methyltransferase. Biochemical and Biophysical Research Communications. 1985;126(3):1201-7. [pmid: 3977911].
Lowenthal A, Meyerstein N, Ben-Zvi Z. Thiopurine methyltransferase activity in the Jewish population of Israel. European Journal of Clinical Pharmacology. 04. 2001;57(1):43-6. [pmid: 11372589].
Lowry PW, Franklin CL, Weaver AL, et al. Measurement of thiopurine methyltransferase activity and azathioprine metabolites in patients with inflammatory bowel disease.[see comment]. Gut. 11. 2001;49(5):665-70. [pmid: 11600469].
Lu HF, Shih MC, Chang YS, et al. Molecular analysis of thiopurine S-methyltransferase alleles in Taiwan aborigines and Taiwanese. Journal of Clinical Pharmacy & Therapeutics. 02. 2006;31(1):93-8. [pmid: 16476125].
Lu HF, Shih MC, Hsueh SC, et al. Molecular analysis of the thiopurine S-methyltransferase alleles in Bolivians and Tibetans. Journal of Clinical Pharmacy & Therapeutics. 10. 2005;30(5):491-6. [pmid: 16164497].
Lysaa RA, Warren DJ, Sylte I, et al. Effect of the glutathione/glutathione disulfide redox couple on thiopurine methyltransferase. Biochemical Pharmacology. 03. 15. 2001;61(6):707-14. [pmid: 11266655].
Martinez F, Nos P, Pastor M, et al. Adverse effects of azathioprine in the treatment of inflammatory bowel disease. Revista Espanola de Enfermedades Digestivas. 2001;93(12):774-8.
Masbou J, Brunschwig C, Hillaire-Buys D, et al. Is hepatic toxic effects of thiopurine derivatives drugs related to TPMT activity deficiency. Journal of Hepatology. 1996;25.
Meggitt SJ, Gray JC, Reynolds NJ. Azathioprine dosed by thiopurine methyltransferase activity for moderate-to-severe atopic eczema: a double-blind, randomised controlled trial. Lancet. 2006;367(9513):839-46. [pmid: 16530578].
Morales A, Salguti S, Miao CL, et al. Relationship between 6-mercaptopurine dose and 6-thioguanine nucleotide levels in patients with inflammatory bowel disease. Inflammatory Bowel Diseases. 2007;13(4):380-5. [pmid: 17206711].
Murphy LA, Atherton D. A retrospective evaluation of azathioprine in severe childhood atopic eczema, using thiopurine methyltransferase levels to exclude patients at high risk of myelosuppression. British Journal of Dermatology. 2002;147(2):308-15. [pmid: 12174104].
Myrelid P, Olaison G, Sjodahl R, et al. Thiopurine therapy is associated with postoperative intra-abdominal septic complications in abdominal surgery for Crohn’s disease. Diseases of the Colon & Rectum. 2009;52(8):1387-94. [pmid: 19617749].
Neurath MF, Kiesslich R, Fischer C, et al. Measurement of 6-thioguanosine mono-, di- and triphosphates for monitoring of azathioprine therapy in IBD. Gastroenterology. 2004;126.
Neurath MF, Kiesslich R, Teichgraber U, et al. Analysis of 6-thioguanosine Di- (TGDP) and triphosphate (TGTP) levels as a novel method for clinical monitoring of azathioprine therapy in Crohn’s disease. Gastroenterology. 2005;128.
Oselin K, Anier K. Inhibition of human thiopurine S-methyltransferase by various nonsteroidal anti-inflammatory drugs in vitro: a mechanism for possible drug interactions. Drug Metabolism & Disposition. 2007;35(9):1452-4. [pmid: 17553913].
Otterness D, Szumlanski C, Woods T, et al. Thiopurine methyltransferase (TPMT) pharmacogenetics: Mechanism for loss of activity by a splice junction variant allele. Clinical Pharmacology and Therapeutics. 1998;63(2).
Otterness DM, Szumlanski CL, Wood TC, et al. Human thiopurine methyltransferase pharmacogenetics. Kindred with a terminal exon splice junction mutation that results in loss of activity. Journal of Clinical Investigation. 1998;101(5):1036-44. [pmid: 9486974].
Pacifici GM, Romiti P, Santerini S, et al. S-methyltransferases in human intestine: differential distribution of the microsomal thiol methyltransferase and cytosolic thiopurine methyltransferase along the human bowel. Xenobiotica. 1993;23(6):671-9. [pmid: 8212740].
Paerregaard A, Schmiegelow K. Measurement of thiopurine methyl transferase (TPMT) activity and azathioprine metabolites in childhood IBD treatment. JPGN. 2000;31.
Panchal PC, Zielman CJ, Schuhmacher C, et al. Allopurinol favorably affects AZA/6MP metabolism by lowering 6-MMP levels in patients with hepatoxicity from AZA/6MP without affecting red blood cell thiopurine methyltransferase (TMPT) activity. Gastroenterology. 2006;130.
Pettersson B, Soderhaell S, Almer S, et al. Role of thiopurine methyltransferase (TPMT) for the cytotoxicity of thiopurines. Proceedings of the American Association for Cancer Research Annual Meeting. 1999;40.
Provenzale D, Onken JE. TPMT genotype screening for patients about to begin azathioprine treatment--a look at costs and potential benefits. Inflammatory Bowel Diseases. 2005;11(12):1119-20. [pmid: 16306775].
Ramasamy S, Picton R, Langman M, et al. Thiopurine methyltransferase activity in rectal mucosa and erythrocytes in IBD. Gut. 2005;54.
Regueiro M, Mardini H. Determination of thiopurine methyltransferase genotype or phenotype optimizes initial dosing of azathioprine for the treatment of Crohn’s disease. Journal of Clinical Gastroenterology. 2002;35(3):240-4. [pmid: 12192200].
Regueiro MD, Mardini HE. Determining the thiopurine methyltransferase (TPMT) genotype minimizes the risk of acute myelosuppression and maximizes the initial dosing of azathioprine for the treatment of Crohn’s disease. Gastroenterology. 2001;120.
Reinshagen M, Schutz E, Armstrong VW, et al. 6-thioguanine nucleotide-adapted azathioprine therapy does not lead to higher remission rates than standard therapy in chronic active crohn disease: results from a randomized, controlled, open trial.[see comment]. Clinical Chemistry. 2007;53(7):1306-14. [pmid: 17495015].
Roblin X, Biroulet LP, Phelip JM, et al. Erratum: A 6-thioguanine nucleotide threshold level of 400 pmol/8 x 10 8 erythrocytes predicts azathioprine refractoriness in patients with inflammatory bowel disease and normal TPMT activity. American Journal of Gastroenterology. 2009;104(4):1072.
Rumbo C, Emerick KM, Emre S, et al. Azathioprine metabolite measurements in the treatment of autoimmune hepatitis in pediatric patients: a preliminary report. Journal of Pediatric Gastroenterology & Nutrition. 2002;35(3):391-8. [pmid: 12352536].
Sans M, Bufadel ME, Cara C, et al. Determination of thiopurine methyltransferase (TPMT) activity in patients with inflammatory bowel disease (IBD) treated with azathioprine. Gastroenterology. 2002;122(4 Suppl 1):A-222.
Seiderer J, Remisch W, Zech C, et al. Nodular regenerative hyperplasia in IBD patients on 6-thioguanine - a multicentre safety assessment by MRI and liver biopsy. Gastroenterology. 2004;126.
Seidman EG, Girardin M, Anne D, et al. 6MMP/6TGN metabolite ratios predict therapeutic outcomes and reflect thiopurine methyltransferase genotype in IBD. Gastroenterology. 2007;132.
Serpe L, Calvo PL, Muntoni E, et al. Thiopurine S-methyltransferase pharmacogenetics in a large-scale healthy Italian-Caucasian population: Differences in enzyme activity. Pharmacogenomics. 2009;10(11):1753-65. [pmid: 19891552].
Sheffield LJ, Irving P, Gupta A, et al. Thiopurine methyltransferase and thiopurine metabolite testing in patients with inflammatory bowel disease who are taking thiopurine drugs. Pharmacogenomics. 2009;10(7):1091-9. [pmid: 19604082].
Sies C, Florkowski C, George P, et al. Measurement of thiopurine methyl transferase activity guides dose-initiation and prevents toxicity from azathioprine. New Zealand Medical Journal. 2005;118(1210):U1324. [pmid: 15776100].
Slanar O, Bortlik M, Buzkova H, et al. Polymorphisms of the TPMT gene in the Czech healthy population and patients with inflammatory bowel disease. Nucleosides, Nucleotides & Nucleic Acids. 2008;27(6):835-8.
Smith M, Marinaki A, Arenas M, et al. Myelotoxicity is a late event in azathioprine treated TPMT heterozygotes. Gut. 2007;56.
Smith M, Marinaki T, Ansari A, et al. Common polymorphism in the aldehyde oxidase gene is a marker of non-response to azathioprine therapy in inflammatory bowel disease. Gut. 2008;57.
Smith M, Marinaki T, Ansari A, et al. Seeking pharmacogenetic loci which explain non-thiopurine methyltransferase related side effects in patients taking azathioprine for inflammatory bowel disease. Gut. 2008;57.
Smith MA, Marinaki AM, Arenas M, et al. Novel pharmacogenetic markers for treatment outcome in azathioprine-treated inflammatory bowel disease. Alimentary Pharmacology and Therapeutics. 2009;30(4):375-84. [pmid: 19500084].
Smith M, Marinaki AM, Arenas M, et al. Myelotoxicity is a late event in azathioprine-treated tpmt heterozygotes: Lessons for monitoring. Gastroenterology. 2007;132(4, Suppl 2):A179-A180.
Stolk JN, Boerbooms AM, De Abreu RA, et al. Purine enzyme activities in recent onset rheumatoid arthritis: are there differences between patients and healthy controls?. Annals of the Rheumatic Diseases. 1996;55(10):733-8. [pmid: 8984938].
Stolk JN, de Koning DG, Pennings AH, et al. Reduced purine 5′-nucleotidase activity in lymphocytes of patients with systemic lupus erythematosus: results of a pilot study. Annals of the Rheumatic Diseases. 02. 1999;58(2):122-5. [pmid: 10343529].
Szumlanski C, Otterness D, Her C, et al. Thiopurine methyltransferase pharmacogenetics: human gene cloning and characterization of a common polymorphism. DNA & Cell Biology. 1996;15(1):17-30. [pmid: 8561894].
Szumlanski CL, Scott MC, Weinshilboum RM. Thiopurine Methyltransferase Tpmt Pharmacogenetics Human Liver Enzyme Activity. Clinical Pharmacology and Therapeutics. 1988;43(2).
Szumlanski CL, Weinshilboum RM. Sulphasalazine inhibition of thiopurine methyltransferase: possible mechanism for interaction with 6-mercaptopurine and azathioprine. British Journal of Clinical Pharmacology. 1995;39(4):456-9. [pmid: 7640156].
Szumlanski C, Weinshilboum RM. Sulfasalazine inhibition of thiopurine methyltransferase (TPMT): Possible mechanism for interaction with 6-mercaptopurine (6-MP). Clinical Pharmacology and Therapeutics. 1995;57(2).
Tai HL, Fessing MY, Bonten EJ, et al. Enhanced proteasomal degradation of mutant human thiopurine S-methyltransferase (TPMT) in mammalian cells: mechanism for TPMT protein deficiency inherited by TPMT*2, TPMT*3A, TPMT*3B or TPMT*3C. Pharmacogenetics. 10. 1999;9(5):641-50. [pmid: 10591545].
Tai HL, Krynetski EY, Schuetz EG, et al. Enhanced proteolysis of thiopurine S-methyltransferase (TPMT) encoded by mutant alleles in humans (TPMT*3A, TPMT*2): mechanisms for the genetic polymorphism of TPMT activity. Proceedings of the National Academy of Sciences of the United States of America. 1997;94(12):6444-9. [pmid: 9177237].
Takatsu N, Matsui T, Murakami Y, et al. Adverse reactions to azathioprine cannot be predicted by thiopurine S-methyltransferase genotype in Japanese patients with inflammatory bowel disease. Journal of Gastroenterology and Hepatology. 2009;24(7):1258-64. [pmid: 19682195].
Uchiyama K, Nakamura M, Kubota T, et al. Thiopurine S-methyltransferase and inosine triphosphate pyrophosphohydrolase genes in Japanese patients with inflammatory bowel disease in whom adverse drug reactions were induced by azathioprine/6-mercaptopurine treatment. Journal of Gastroenterology. 2009;44(3):197-203. [pmid: 19214663].
Yip JS, Woodward M, Abreu MT, et al. How are Azathioprine and 6-mercaptopurine dosed by gastroenterologists? Results of a survey of clinical practice. Inflammatory Bowel Diseases. 2008;14(4):514-8. [pmid: 18088072].

## Excluded at Level III (i.e. not for Q1a or 1b, and not identified previously at level II for any other key question), n = 35

### No direct pre-analytic data of relevance, n=32

Alves S, Prata MJ, Ferreira F, et al. Thiopurine methyltransferase pharmacogenetics: alternative molecular diagnosis and preliminary data from Northern Portugal. Pharmacogenetics. 04. 1999;9(2):257-61. [pmid: 10376773].
Ashavaid TF, Raghavan R, Shah S, et al. TPMT and DPD polymorphisms: Efficient screening method for Indian patients considering taking Thiopurine and 5-FU drugs. Disease Markers. 2009;27(5):231-238. Date of Publication: 2009. [pmid: 20037211]. 2009;(5):231-8.
Bakre EMS, Duley JA. Non-radioactive, HPLC-based assay of lymphocyte purine 5-nucleotidase: A predictor of azathioprine sensitivity. Journal of Inherited Metabolic Disease. 1996;19.
Barstad P. Method of determining thiopurine methyltransferase activity. Official Gazette of the United States Patent and Trademark Office Patents. 2006.
Boulieu R, Sauviat M, Dervieux T, et al. Phenotype determination of thiopurine methyltransferase in erythrocytes by HPLC. Clinical Chemistry. 05. 2001;47(5):956-8. [pmid: 11325909].
Cheng Q, Yang W, Raimondi SC, et al. Karyotypic abnormalities create discordance of germline genotype and cancer cell phenotypes.[see comment]. Nature Genetics. 08. 2005;37(8):878-82. [pmid: 16041371].
Coulthard S, Hogarth L. The thiopurines: an update. [Review] [101 refs]. Investigational New Drugs. 12. 2005;23(6):523-32. [pmid: 16267626].
Daperno M, Sostegni R, Canaparo R, et al. Mesalamine does not impact on thiopurine-methyl-transferase (TPMT) activity in inflammatory bowel disease (IBD) patients. Gastroenterology. 2008;134(4, Suppl 1):A205-A206.
Deininger M, Szumlanski CL, Otterness DM, et al. Purine substrates for human thiopurine methyltransferase. Biochemical Pharmacology. 11. 29. 1994;48(11):2135-8. [pmid: 7802704].
Dervieux T, Boulieu R. A HPLC method for the monitoring of human red cell 6-thioguanine and methyl 6-mercaptopurine in a single run. Advances in Experimental Medicine and Biology. 1998;431:729-734. [pmid: 9598160].
Dewit O, Vanheuverzwyn R, Desager JP, et al. Interaction between azathioprine and aminosalicylates: An in vivo study in patients with Crohn’s disease. Gastroenterology. 2001;120.
Dunnette J, Chelgren SS, Woodson LC, et al. Human thiopurine methyltransferase (TPMT) biochemical genetics. Pharmacologist. 1981;23(3).
Fakhoury M, ndreu-Gallien J, Mahr A, et al. Should TPMT genotype and activity be used to monitor 6-mercaptopurine treatment in children with acute lymphoblastic leukaemia?. Journal of Clinical Pharmacy & Therapeutics. 12. 2007;32(6):633-9. [pmid: 18021342].
Gardiner SJ, Begg EJ, Barclay ML, et al. Genetic polymorphism and outcomes with azathioprine and 6-mercaptopurine. Adverse Drug Reactions and Toxicological Reviews. 2000;19(4):293-312. [pmid: 11212460].
Ishiguro A, Kubota T, Soya Y, et al. High-throughput detection of multiple genetic polymorphisms influencing drug metabolism with mismatch primers in allele-specific polymerase chain reaction.[erratum appears in Anal Biochem. 2005 Aug 15;343(2):359]. Analytical Biochemistry. 02. 15. 2005;337(2):256-61. [pmid: 15691505].
Kapoor G, Maitra A, Somlata, et al. Application of SNaPshot for analysis of thiopurine methyltransferase gene polymorphism. Indian Journal of Medical Research. 2009;129(5):500-5. [pmid: 19675376].
Kroplin T, Fischer C, Iven H. Inhibition of thiopurine S-methyltransferase activity by impurities in commercially available substrates: a factor for differing results of TPMT measurements. European Journal of Clinical Pharmacology. 06. 1999;55(4):285-91. [pmid: 10424321].
Milek M, Murn J, Jaksic Z, et al. Thiopurine S-methyltransferase pharmacogenetics: genotype to phenotype correlation in the Slovenian population. Pharmacology. 2006;77(3):105-14. [pmid: 16691038].
Nishida A, Kubota T, Yamada Y, et al. Thiopurine S-methyltransferase activity in Japanese subjects: metabolic activity of 6-mercaptopurine 6-methylation in different TPMT genotypes. Clinica Chimica Acta. 09. 2002;323(1–2):147-50.
Okada Y, Nakamura K, Wada M, et al. Genotyping of thiopurine methyltransferase using pyrosequencing. Biological & Pharmaceutical Bulletin. 04. 2005;28(4):677-81. [pmid: 15802809].
Otterness D, Szumlanski C, Lennard L, et al. Human thiopurine methyltransferase pharmacogenetics: gene sequence polymorphisms. Clinical Pharmacology & Therapeutics. 07. 1997;62(1):60-73. [pmid: 9246020].
Padhye NV, Quintanar A, Nelson R. Rapid, immunochemical process for measuring thiopurine methyltransferase. Official Gazette of the United States Patent and Trademark Office Patents. 2005.
Piatkov I, Ma G, Li S, et al. Effective screening for thiopurine methyltransferase polymorphism in patients at risk of toxicity on thiopurine therapy. Australian Journal of Medical Science. 2006;27(3):113-7.
Pike MG, Franklin CL, Mays DC, et al. Improved methods for determining the concentration of 6-thioguanine nucleotides and 6-methylmercaptopurine nucleotides in blood. Journal of Chromatography. 2001. 06. 5. B, Biomedical Sciences & Applications. 757(1):1-9.
Roberts RL, Barclay ML, Gearry RB, et al. A multiplexed allele-specific polymerase chain reaction assay for the detection of common thiopurine S-methyltransferase (TPMT) mutations. Clinica Chimica Acta. 03. 2004;341(1–2):49-53.
Schaeffeler E, Eichelbaum M, Reinisch W, et al. Three novel thiopurine S-methyltransferase allelic variants (TPMT*20, *21, *22) - association with decreased enzyme function. Human Mutation. 09. 2006;27(9):976. 2006. [pmid: 16917910].
Schaeffeler E, Lang T, Zanger UM, et al. High-throughput genotyping of thiopurine S-methyltransferase by denaturing HPLC. Clinical Chemistry. 03. 2001;47(3):548-55. [pmid: 11238310].
Spire-Vayron de la Moureyre, Debuysere H, Mastain B, et al. Genotypic and phenotypic analysis of the polymorphic thiopurine S-methyltransferase gene (TPMT) in a European population. British Journal of Pharmacology. 10. 1998;125(4):879-87. [pmid: 9831928].
Van Loon JA, Weinshilboum RM. Thiopurine methyltransferase biochemical genetics: human lymphocyte activity. Biochemical Genetics. 08. 1982;20(7–8):637-58. [pmid: 7138494].
Weinshilboum RM, Sladek SL. Mercaptopurine pharmacogenetics: monogenic inheritance of erythrocyte thiopurine methyltransferase activity. American Journal of Human Genetics. 09. 1980;32(5):651-62. [pmid: 7191632].
Yan L, Zhang S, Eiff B, et al. Thiopurine methyltransferase polymorphic tandem repeat: genotype-phenotype correlation analysis. Clinical Pharmacology & Therapeutics. 08. 2000;68(2):210-9. [pmid: 10976552].
Yates CR, Krynetski EY, Loennechen T, et al. Molecular diagnosis of thiopurine S-methyltransferase deficiency: genetic basis for azathioprine and mercaptopurine intolerance.[see comment]. Annals of Internal Medicine. 04. 15. 1997;126(8):608-14. [pmid: 9103127].

### Non-original data, n=1

Bergan S, Rugstad HE, Klemetsdal B, et al. Possibilities for therapeutic drug monitoring of azathioprine: 6-thioguanine nucleotide concentrations and thiopurine methyltransferase activity in red blood cells. Therapeutic Drug Monitoring. 06. 1997;19(3):318-26. [pmid: 9200774].

### No proficiency, reproducibility and precision data, n=4

Barstad P. Method of determining thiopurine methyltransferase activity. Official Gazette of the United States Patent and Trademark Office Patents. 2006.
Dervieux T, Meyer G, Matsutani M, et al. Liquid chromatography tandem mass spectrometry of erythrocyte thiopurine nucleotides: Application at the thiopurine methyltransferase gene locus. Clinical Chemistry. 2005;51.
Nishida A, Kubota T, Yamada Y, et al. Thiopurine S-methyltransferase activity in Japanese subjects: metabolic activity of 6-mercaptopurine 6-methylation in different TPMT genotypes. Clinica Chimica Acta. 09. 2002;323(1–2):147-50.
Tomkova J, Friedecky D, Polynkova A, et al. Capillary electrophoresis determination of thiopurine methyl transferase activity in erythrocytes. Journal of Chromatography B: Analytical Technologies in the Biomedical and Life Sciences. 2009;877(20–21):1943-5.

### Included Records not reporting relevant data for any key question, n=33

Allan M, Tendler D, Muir A, et al. Utility of thiopurine methyltransferase pharmacogenetic testing and monitoring of azathioprine metabolites in the management of autoimmune hepatitis. Gastroenterology. 2002;122.
Alves S, Prata MJ, Ferreira F, et al. Screening of thiopurine S-methyltransferase mutations by horizontal conformation-sensitive gel electrophoresis. Human Mutation. 2000;15(3):246-53. [pmid: 10679940].
Ansari AR, Soon SY, Lindsay J, et al. Thiopurine methyl transferase activity predicts both toxicity and clinical response to azathioprine in inflammatory bowel disease: The London IBD forum prospective study. Gastroenterology. 2004;126.
Bastida G, Nos P, Aguas M, et al. Incidence, risk factors and clinical course of thiopurine-induced liver injury in patients with inflammatory bowel disease. Alimentary Pharmacology and Therapeutics. 2005;22(9):775-82. [pmid: 16225485].
Campbell S, Kingstone K, Ghosh S. Relevance of thiopurine methyltransferase activity in inflammatory bowel disease patients maintained on low-dose azathioprine. Alimentary Pharmacology & Therapeutics. 03. 2002;16(3):389-98. [pmid: 11876691].
Chowdhury J, Kagiala GV, Pushpakom S, et al. Microfluidic platform for single nucleotide polymorphism genotyping of the thiopurine S-methyltransferase gene to evaluate risk for adverse drug events. Journal of Molecular Diagnostics. 09. 2007;9(4):521-9. [pmid: 17690215].
Colletti RB, Baldassano RN, Milov DE, et al. Variation in care in pediatric crohn disease. J Pediatr Gastroenterol Nutr. 09. 2009;49(3):297-303. [pmid: 19590456].
Comer M, James I, D’Cruz D, et al. Erythrocyte thiopurine methyltransferase (TPMT) activity in rheumatoid arthritis patients experiencing azathioprine haematological toxicity. British Journal of Rheumatology. 1998;37.
Cuffari C, Dassopoulos T, Turnbough L, et al. Thiopurine methyltransferase activity influences clinical response to azathioprine in inflammatory bowel disease. Clinical Gastroenterology & Hepatology. 05. 2004;2(5):410-7. [pmid: 15118980].
Curvers W, Derijks L, Stokkers P, et al. No Predictive Value of Tpmt Genotyping for Leukopenia Or Hepatotoxicity During Azathioprine Therapy in Inflammatory Bowel Disease. Digestive Disease Week Abstracts and Itinerary Planner. 2003.
Curvers W, Gilissen L, Derijks L, et al. Pharmacokinetic Analysis of 6-Mercaptopurine in Patients with Inflammatory Bowel Disease. Digestive Disease Week Abstracts and Itinerary Planner. 2003.
Daperno M, Canaparo R, Sostegni R, et al. Genotype and phenotype analysis of thiopurine-methyl-transferase (TPMT) in a northern Italian. Gastroenterology. 2008;134.
Domenech E, Garcia-Planella E, Fluvia L, et al. Clinical Implications of Thiopurine-Methyltransferase Activity (Tpmte) Induction by Azathioprine (Aza) Treatment in Patients with Inflammatory Bowel Disease (Ibd). Digestive Disease Week Abstracts and Itinerary Planner. 2003.
Gubanich P, Achkar DP, Lashner B, et al. Thiopurine methyl transferase (TPMT) phenotype as a predictor of clinical response and side effect profile in a population of IBD patients. American Journal of Gastroenterology. 2004;99(10, Suppl S):S269-S270.
Heneghan MA, Allan ML, Bornstein JD, et al. Utility of thiopurine methyltransferase genotyping and phenotyping, and measurement of azathioprine metabolites in the management of patients with autoimmune hepatitis. Journal of Hepatology. 10. 2006;45(4):584-91. [pmid: 16876902].
Hurlburt K, Mayo M, Yeo A, et al. TPMT activity related to azathioprine dosing and treatment of autoimmune hepatitis. Hepatology. 2005;42(4, Suppl 1):291A.
Katsanos K, Ferrante M, Joossens M, et al. The MDR1 G2677T polymorphism is associated with gastrointestinal intolerance to azathioprine. Gastroenterology. 2006;130(4, Suppl 2):A199-A200.
Kerstens PJ, Stolk JN, De Abreu RA, et al. Azathioprine-related bone marrow toxicity and low activities of purine enzymes in patients with rheumatoid arthritis. Arthritis & Rheumatism. 01. 1995;38(1):142-5. [pmid: 7818564].
Kwan LY, Devlin SM, Mirocha JM, et al. Thiopurine methyltransferase activity combined with 6-thioguanine metabolite levels predicts clinical response to thiopurines in patients with inflammatory bowel disease. Digestive & Liver Disease. 06. 2008;40(6):425-32. [pmid: 18304898].
Moloney M, Langley P, McFarlane I. Azathioprine tolerance is related to TPMT activity in autoimmune hepatitis (AIH). Gastroenterology. 1997;112.
Naughton MA, Battaglia E, O’Brien S, et al. Identification of thiopurine methyltransferase (TPMT) polymorphisms cannot predict myelosuppression in systemic lupus erythematosus patients taking azathioprine. Rheumatology. 07. 1999;38(7):640-4. [pmid: 10461478].
Pageaux G, Masbou J, Brunschwig C, et al. Are hepatic toxic effects of thiopurine derivatives drugs related to thiopurine methyltransferase activity deficiency. Gastroenterology. 1997;112.
Qasim A, Molley C, McLoughlin R, et al. Absolute Leukocyte Count and Its Correlation with Thiopurine Methyl Transferase (Tpmt) Activity in Inflammatory Bowel Disease (Ibd) Patients Receiving Azathioprine (Aza)/6-Mercaptopurine (6Mp). Digestive Disease Week Abstracts and Itinerary Planner. 2003.
Rietdijk ST, Bartelsman J, Hommes DW, et al. Genetic polymorphisms of the thiopurine S-methyltransferase (TPMT) locus in patients treated with azathioprine for inflammatory bowel disease. Gastroenterology. 2001;120.
Schaeffeler E, Zanger UM, Eichelbaum M, et al. Highly multiplexed genotyping of thiopurine s-methyltransferase variants using MALD-TOF mass spectrometry: reliable genotyping in different ethnic groups.[see comment]. Clinical Chemistry. 10. 2008;54(10):1637-47. [pmid: 18687736].
Shobowale-Bakre M, Hassan C, Ansari A, et al. Predicting drug toxicity and non-response: Azathioprine and thiopurine methyltransferase as a metabolic model. Journal of Inherited Metabolic Disease. 2000;23.
Stolk J, Boerbooms A, De Abreu R, et al. The predictive value of thiopurine-methyltransferase activity for the development of toxicity of azathioprine in the treatment of rheumatoid arthritis. British Journal of Rheumatology. 1997;36.
Taylor E, Matsutani M, Barry M, et al. TPMT (thiopurine methyltransferase) genotype-phenotype accuracy in IBD patients. Gastroenterology. 2002;122(4 Suppl 1):A-222.
Vestergaard T, Bygum A. An audit of thiopurine methyltransferase genotyping and phenotyping before intended azathioprine treatment for dermatological conditions. Clinical and Experimental Dermatology. 2010;35(2):140-4. [pmid: 19663853].
Walsh M, Royston C, Srinivas M, et al. Monitoring azathioprine (AZA) treatment in inflammatory bowel disease (IED): Rituals RE-visited but not revised!. Gastroenterology. 2008;134(4 Suppl 1).
Watanabe K, Simmons J, Orchard T, et al. Allelic variants of thiopurine methyl transferase are associated with azathioprine induced leukopaenia. Gut. 2000;46(11).
Wong JL, Lowes J, Biggs L, et al. The role of thiopurine methyltransferase (TPMT) activity assay before commencing thiopurine drugs in inflammatory bowel disease (IBD). Gastroenterology. 2002;122(4 Suppl 1):A-222.
Zelinkova Z, Derrijks L, Stokkers P, et al. Inosine triphosphate pyrophosphatase gene mutation predicts myelosuppression in IBD patients treated with azathioprine. Gastroenterology. 2004;126.