# Evidence Tables

Additional data are presented here for Key Questions 1b, 1c, 2, 3a, 3b, 3c and 4 Reference list is provided at the end of the document

## Key Question 1b Within and between laboratory precision and reproducibility of enzymatic measurement of TPMT and determination of TPMT allelic polymorphisms

Table C-1 KQ 1b: Precision and reproducibility of TPMT status determinations

Study | Full or partial industry funding | Study region | TPMT activity assay method particulars^*^ | Inter-assay coefficient of variance (%) | Intra-assay coefficient of variance (%)
HPLC TPMT assays Unless otherwise noted, TPMT is measured as the formation of 6-MMP from 6-MP, using nonradio-labelled SAM for the methyl donor, in RBC lysates.1,2
Lennard 2001^3^ | No | Europe | HPLC TPMT assay previously described2,4 | 5–9% | 6.3%
Jacqz-Aigrain, 1994^1^ | NR | Europe | HPLC TPMT assay | 6.2% (n=5) | 8.9% (n=5)
Indjova 2003^5^ | NR | Europe | HPLC TPMT assay | 4.4–4.9% | 6.8%
Shipkova 2004^6^ | NR | Europe | HPLC TPMT assay | Pooled RBC: 5%; Control: 2.4% | Pooled RBC: 7.6%; Control: 2.4%
Zhang 2007^7^ | No | Asia | HPLC TPMT assay | Control: 4.29%; Author control: 3.29% | Control: 4.29%; Author control: 3.25%
Indjova 2003^8^ | NR | Europe | HPLC TPMT assay previously described5. | Pooled RBC: <5% Control: <2.4% | Pooled RBC: <7.6% Control: <2.4%
Anglicheau 2002^9^ | NR | Europe | HPLC TPMT assay; - No extraction step. | 6.0% (n=5) | 9.5% (n=5)
Dervieux 2001^10^ | No | Europe | HPLC TPMT assay previously described1. | 2.6% (n=5) | 5.2% (n=8)
Dervieux 1999^11^ | No | Europe | HPLC TPMT assay previously described1,12 | 2.6% (n=5) | 5.2% (n=8)
Menor 2001^13^ | No | Europe | HPLC TPMT assay | 2.4–2.8% | 4.2–6.3%
Ganiere-Monteil 1999^14^ | NR | Europe | HPLC TPMT assay with liquid–liquid extraction using a pH 9.5 NH_4_Cl buffer | 6.1% (n=56) | 9,5% (n=56)
Escousse 1998^15^ | NR | Europe | HPLC assay previously described1,16 | 8.4–9.4% (n=3) | 0–8.2% (n=5)
Medard 1997^12^ | NR | Europe | HPLC TPMT assay previously described1.; - Following incubation, liquid-liquid extraction replaced liquid-solid extraction.; - Improved chromatographic conditions. | 6.7–10.2% (n=21) | 2.7–6.9% (n=5)
Johnson-Davis 2008^17^ | NR | North America | HPLC TPMT assay | 0.2–0.8% (n=20) | 3.2–8.7% (n=20)
Khalil 2005^18^ | | Europe | HPLC TPMT assay; - Simplified by eliminating time consuming extraction steps with organic solvents, a heating step and gradient elution. | 1.4–4.9% (n=10) | 1% (n=12)
Ganiere-Monteil 2004^19^ | NR | Europe | HPLC TPMT assay previously described1,14. | 1.7–4.3% (n=6) | 0.8–6.0% (n=6)
Zhang 2006^20^ | NR | Asia | HPLC TPMT assay previously described.1,14 | 4.29% | 4.29%
Keizer-Garritsen 2003^21^ | NR | Europe | HPLC TPMT assay | Between day (n=5): Supernatants were stored at − 23°C. Initial activities: 17.2±1.6, 38.5±2.4, 17.6±2.1, 15.9±1.4, 12.2±2.1 pmol/h/10^7^ RBCs. After 7 days: 19.2±1.4, 36.4±2.1, 17.0±1.8, 19.1±2.5, 12.8±2.4 pmol/h/10^7^ RBCs. After 25 days stored at −80°C: 17.0±2.2, 34.0±2.6, 15.5±2.4, 16.6±1.8, 10.6±1.6 pmol/h/10^7^ RBCs. | 15.0±1.4 and 22.4±2.0 pmol/h/10^7^ RBCs (n=2).
Oselin 2006^22^ | No | Europe | HPLC TPMT assay | Precision 4% | Accuracy 96–103%.
Kroplin 1998^23^ | NR | Europe | HPLC TPMT assay to measure 6-MTG in RBC lysates. | 5% (n=20) | 6.7% (n=36)
Lentz 2000^24^ | NR | North America | HPLC TPMT assay to measure 6-MTG formed from 6-TG in whole blood and RBC lysates. | 2–3% | 4–10%
Ford 2006^25^ | No | Europe | HPLC TPMT assay to measure 6-MTG formed from 6-TG in whole blood and RBC lysates. | Standard RBCs: 3.6% (n=10) Whole blood: 2.7% (n=10) | Standard RBCs: 8.0% (n=20); Whole blood: 7.6% (n=20)
Ford 2004^26^ | Yes | Europe | HPLC TPMT assay to measure 6-MTG in RBC lysates. | 3.4% (n=20) | 9.1% (n=37)
Decaux 2001^27^ | Yes | Europe | HPLC TPMT assay to measure 6-MTG in RBC lysates. | 4.1–4.5% (n=6) | 6.9–8% (n = 17)

Abbreviations: 6-MP = 6-mercaptopurine; 6-MMP = 6-methyl mercaptopurine; 6-MTG = 6-methylthioguanine; HPLC = high pressure liquid chromatography; RBCs = red blood cells; SAM = S-adenosyl-L-methionine; SEM = standard error of means; TPMT = thiopurine methyl transferase.

## Key Question 1c Diagnostic sensitivity and specificity of TPMT allelic polymorphism measurement, compared with the measurement of TPMT enzymatic activity

Table C-2 KQ1c: Diagnostic sensitivity and specificity of TPMT determinations – patient and study characteristics, part 1

Study | Study Region Study Setting Study Design | Inclusion and exclusion criteria | Thiopurine treatment Concomitant treatments | TPMT activity testing method | TPMT activity range and cut-off values | Genotyping method | SNPs Genotyped
Ansari, 2008^28^ | Europe Outpatient specialty clinic Non-randomized intervention study | Exclusion: 18–80 years of age; previous history of thiopurine or biologics use; very low TPMT activity | AZA 5-ASA, steroids | Mass spectrometry | Low 0–10 U/g Hb Intermediate 11–25 U/g Hb Normal 26–50 U/g Hb | NR | TPMT*3A, *3B, *3C
Ansari, 2002^29^ | NR Outpatient specialty clinic Cross-sectional | Inclusion: Diagnosis of IBD; current or past treatment with AZA. Exclusion: Reliable data on clinical response or adverse effects not available. | AZA 5-ASA, steroids | Radioassay | Low <2.5 U/mL RBC Intermediate 2.5–7.5 U/mL RBC High >7.5 U/mL RBC | Polymerase chain reaction | TPMT*2, *3A, *3C
Gardiner, 2008^30^ | Oceania Inpatient and outpatient specialty clinics Prospective observational | Inclusion: Diagnosis of IBD; normal or intermediate TPMT activity; first time treatment with AZA or 6-MP. Exclusion: Pre-existing neutropenia | AZA, 6-MP 5-ASA | Radioassay | Normal 9.3–17.6 U/mL RBC Intermediate 5–9.2 U/mL RBC | Polymerase chain reaction | TPMT*2, *3A, *3C
Haglund, 2004^31^ | Europe NR Cross-sectional | NR | Mixed thiopurines 5-ASA, steroids | Radioassay | Low <5.0 U/mL RBC Intermediate 5.0–9.0 U/mL RBC Normal >9.0 U/mL RBC | Pyrosequencing | TPMT*2, *3A, *3B, *3C, *3D, *4, *5, *6, *7, *8
Hindorf, 2006^32^ | Europe NR Cross-sectional | Inclusion: Diagnosis of IBD; history of Metabolite or TPMT measurements between 2003 and 2007; current or past treatment with thiopurines. | AZA 5-ASA, steroids | Radioassay | Low <2.5 U/mL RBC Intermediate 2-5-8.9 U/mL RBC Normal >9.0 U/mL RBC | Pyrosequencing | TPMT*2, *3A, *3B, *3C, *3D, *4, *5, *6, *7, *8, 10, *14, *15
Hindorf, 2004^33^ | Europe NR Prospective observational | Inclusion: Diagnosis of IBD; current treatment with AZA or 6-MP for at least 4 months and unchanged dose for at least 3 months. Exclusion: Repeatedly low or immeasurable metabolite levels. | AZA, 6-MP 5-ASA | Radioassay | NR | Polymerase chain reaction | TPMT*3A, *3B, *3C, *3D
Langley, 2002^34^ | Europe Outpatient specialty clinic Cross-sectional | Inclusion: Diagnosis of autoimmune hepatitis; hypergammaglobuliemia, elevated serum aminotransferase and liver biopsies. Exclusion: Possible causes of liver disease. | AZA steroids | Radioassay | Low <5.0 U/mL RBC Intermediate 5.0–13.7 U/mL RBC High >13.7 U/mL RBC | Polymerase chain reaction | TPMT*3A, *3B, *3C
Lindqvist, 2006^35^ | Europe Outpatient specialty clinic Prospective observational | Exclusion: Recent thiopurine therapy; history of pancreatitis with thiopurines; pregnancy; breastfeeding | AZA, 6-MP 5-ASA, steroids | Radioassay | Low <3 U/mL RBC Intermediate 3–8.9 U/mL RBC Normal/high >8.9 U/mL RBC | Pyrosequencing | TPMT*2, *3A, *3B, *3C, *3D, *4, *5, *6, *7, *8, 10, *14, *15
Marinaki, 2003^36^ | Europe Outpatient specialty clinic Cross-sectional | Inclusion: Diagnosis of IBD; East Indian or Pakistani heritage | AZA NR | Radioassay | Low >2.5 U/g Hb Intermediate 2.5–7.5 U/g Hb Normal 7.6–14.5 U/g Hb | Polymerase chain reaction | TPMT*2, *3A, *3C
Okada, 2005^37^ | Asia NR Cross-sectional | Inclusion: Diagnosis of SLE; current or past treatment with AZA | AZA NR | High performance liquid chromatography | NR | Polymerase chain reaction | TPMT*2, *3A, *3B, *3C
Schwab, 2002^38^ | Europe Outpatient specialty clinic Retrospective review of records | Inclusion Diagnosis of IBD; current or past treatment with AZA. | AZA 5-ASA, steroids, other | High performance liquid chromatography | Low <5 U/mL RBC Intermediate 5–10 U/mL RBC Normal/high: >10 U/mL RBC | Denatured high performance liquid chromatography | TPMT*2, *3A, *3B, *3C, *3D
Snow, 1995^39^ | North America NR Cross-sectional | NR | AZA NR | Radioassay | Low <5 U/mL RBC Intermediate 5–13.7 U/mL RBC High 13.8 to 25.1 U/mL RBC | NR | NR
Stassen, 2009^40^ | NR NR Retrospective review of records | NR | AZA NR | High performance liquid chromatography | Low <2 U/g Hb Intermediate 2–23.5 U/g Hb Normal/high >23.5 U/g Hb | Polymerase chain reaction | TPMT*2, *3A, *3B, *3C
Stocco, 2005^41^ | Europe Outpatient specialty clinic Prospective observational | Inclusion: Diagnosis of IBD; current treatment with a thiopurine for at least 3 months or having experienced an adverse effect during thiopurine treatment | Mixed thiopurines NR | High performance liquid chromatography | Low <4 U/mL RBC Intermediate 4–8U/mL RBC Normal 8–12 U/mL RBC High >12U/mL RBCs | Polymerase chain reaction | TPMT*2, *3A, *3B, *3C
Stocco, 2004^42^ | Europe Outpatient specialty clinic Cross-sectional | Inclusion: Diagnosis of IBD; child or young adult; current or past treatment with thiopurines | AZA NR | High performance liquid chromatography | Intermediate <8.5 U/mL RBC High >8.5 U/mL RBC | Polymerase chain reaction | TPMT*2, *3A, *3B, *3C
von Ahsen, 2005^43^ | Europe NR Randomized controlled trial | Inclusion: Diagnosis of active Crohn’s disease; >18 years; prednisone treatment >300mg during last 4 weeks or relapse within 6 months after steroid pulse therapy. Exclusion: History of cancer; preexisting renal or hepatic disease; pregnancy; breastfeeding | AZA 5-ASA, other | Radioassay | Low <5 U/mL RBC Intermediate 5–9.9 nmol/mL Normal/high >=10 U/mL RBC | Polymerase chain reaction | TPMT*2, *3A, *3B, *3C
Winter, 2007^44^ | Europe NR Cross-sectional | Inclusion: Diagnosis of IBD; current or past treatment with thiopurines. | AZA 5-ASA | Mass spectrometry | Low <10 U/g Hb Intermediate 10–25 U/g Hb Normal 26–50 U/g Hb High >50 U/g Hb | Polymerase chain reaction | TPMT*2, *3A, *3B, * 3C
Newman, 2010^45^ | Europe Outpatient Specialty Clinic Cross-sectional | Nursing and pregnant women, and those likely to experience adverse events were excluded | AZA NR | High performance liquid chromatography | NR | Polymerase chain reaction | TPMT*2, *3A, *3B, * 3C
Hindorf, 2010^46^ | Europe NR Cross-sectional | Inclusion: post treatment AIH scores > 11 | Mixed thiopurines NR | High performance liquid chromatography | Normal: equal or above 9.0 U/mL RBC; Intermediate: 2-5-8.9 U/mL RBC; Low: below 2.5 U/mL RBC | Pyrosequencing | TPMT *2, *3A, *3B, *3C, *3D, *4, *5, *6, *7, *8, and 10 Also *14 and *15

Abbreviations: 5-ASA = 5-aminosalicylates; 6-MP = 6-mercaptopurine; AZA = azathioprine; IBD = inflammatory bowel disease; NR = not reported; RBCs = red blood cells; SLE = systemic lupus erythematosus; SNP = single nucleotide polymorphism; TPMT = thiopurine methyltransferase.

Table C-3 KQ1c: Diagnostic sensitivity and specificity of TPMT determinations – patient and study characteristics, part 2

Study | Underlying disease(s) Age group | Age (years) mean (range) (unless otherwise noted) | Females (%) | Number analyzed | Number of dropouts, withdrawals and untested participants | TPMT Activity: Number with non-interpretable test results | Genotyping: Number with non-interpretable test results
Ansari, 2008^28^ | IBD Adults | 40.3 (18 – 80) | 54 | 192 | 23 | NR | NR
Ansari, 2002^29^ | IBD Adults | 44 | 46 | 40 | 0 | NR | NR
Gardiner, 2008^30^ | IBD Adult | 39.2 (35.4– 42.9) | 51 | 68 | 9 | NR | NR
Haglund, 2004^31^ | IBD Mixed | 38 (12–61) | 43 | 30 | 0 | 0 | 0
Hindorf, 2006^32^ | IBD Adults | 28 (18–42) (median) | 47 | 52 | NR | NR | NR
Hindorf, 2004^33^ | IBD Adults | 36 (18–63) | 47 | 55 | 6 | 0 | 0
Langley, 2002^34^ | AIH Mixed | 45 (13–72) (median) | 74 | 53 | 19 | NR | NR
Lindqvist, 2006^35^ | IBD Adults | 40.5 (18–76) | 47 | 60 | NA | NR | NR
Marinaki, 2003^36^ | IBD NR | NR | NR | 85 | NR | NR | NR
Okada, 2005^37^ | SLE NR | NR | NR | 55 | NR | NR | NR
Schwab, 2002^38^ | IBD Adults | 41 (17–71) (median) | 52 | 93 | NR | NR | NR
Snow, 1995^39^ | Autoimmune dermatologic conditions Adults | NR (26–88) | 39 | 26 | 2 | NR | NR
Stassen, 2009^40^ | Anti-neutrophil cytoplasmic antibody associated vasculitis NR | NR | NR | 108 | 0 | NR | NR
Stocco, 2005^41^ | IBD Mixed | 14.2 (0.8–38.8) (median) | 51 | 28 | NR | NR | NR
Stocco, 2004^42^ | IBD Mixed | 16.4 (4–38) | 45 | 27 | NR | NR | NR
von Ahsen, 2005^43^ | IBD Adults | 36 (SD 11.6) | 56 | 71 | 0 | 0 | 0
Winter, 2007^44^ | IBD NR | 45 | 46 | 130 | 14 | 14 | 14
Newman, 2010^45^ | Majority of IBD patients Adults | 42 | 50 | 333 | 11 | NR | NR
Hindorf, 2010^46^ | Autoimmune hepatitis Adults | 55 (35–67) | 80 | 229 | 9 | NR | 0

Abbreviations: AIH = autoimmune hepatitis; IBD = inflammatory bowel disease; NR = not reported; SD = standard deviation; SLE = systemic lupus erythematosus; TPMT = thiopurine methyltransferase.

Table C-4 KQ1c: Diagnostic sensitivity and specificity of TPMT determinations – risk of bias assessment of included studies, part 1

Study | Representative spectrum of patients | Clear Description of selection criteria | Activity assay correctly measures enzyme activities | Whole or random sample administered activity test | TPMT activity test administered independent of genotype results | Independence of TPMT activity and genotyping tests | Genotyping method description clear for replication | TPMT activity test method description clear for replication
Ansari, 2008^28^ | Yes | Clear | Yes | Unclear | Unclear | Yes | Unclear | Clear
Ansari, 2002^29^ | Unclear | Clear | Yes | Yes | Yes | Yes | Clear | Clear
Gardiner, 2008^30^ | No | Clear | Yes | No | Yes | Yes | Clear | Clear
Haglund, 2004^31^ | No | Partially clear | Yes | Yes | Yes | Yes | Clear | Clear
Hindorf, 2006^32^ | Unclear | Clear | Yes | Yes | Yes | Yes | Clear | Clear
Hindorf, 2004^33^ | No | Clear | Yes | Yes | Yes | Yes | Clear | Clear
Langley, 2002^34^ | Unclear | Clear | Yes | Unclear | Yes | Yes | Clear | Clear
Lindqvist, 2006^35^ | Unclear | Clear | Yes | Yes | Yes | Yes | Clear | Clear
Marinaki, 2003^36^ | Unclear | Unclear | Yes | Yes | Yes | Yes | Clear | Clear
Okada, 2005^37^ | Unclear | Unclear | Yes | Unclear | Unclear | Yes | Unclear | Clear
Schwab, 2002^38^ | Unclear | Partially clear | Yes | Yes | Yes | Yes | Clear | Clear
Snow, 1995^39^ | Unclear | Unclear | Yes | Yes | Yes | Yes | Unclear | Clear
Stassen, 2009^40^ | Unclear | Unclear | Yes | Yes | Yes | Yes | Clear | Clear
Stocco, 2005^41^ | Unclear | Clear | Yes | Unclear | Unclear | Yes | Clear | Clear
Stocco, 2004^42^ | Unclear | Partially clear | Yes | Unclear | Unclear | Yes | Clear | Clear
von Ahsen, 2005^43^ | Unclear | Clear | Yes | Yes | Yes | Yes | Clear | Clear
Winter, 2007^44^ | Unclear | Unclear | Yes | Yes | Yes | Yes | Clear | Clear
Newman, 2010^45^ | Unclear | Clear | Yes | Yes | Yes | Yes | Yes | Yes
Hindorf, 2010^46^ | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | Yes

Abbreviations: TPMT = thiopurine methyltransferase.

Table C-5 KQ1c: Diagnostic sensitivity and specificity of TPMT determinations – risk of bias assessment of included studies, part 2

Study | TPMT activity test results assessed independent of genotyping results | Genotyping results assessed independent of TPMT activity test results | Clinical data availability before assessing activity or genotyping was routine | Reporting of uninterpretable test results | Explanation provided for study withdrawals | HWE Tested | Applicability | Summary risk of bias assessment
Ansari, 2008^28^ | Unclear | Unclear | Unclear | No | Yes | Yes | Applicable | Fair - Unclear if TPMT testing was blinded.
Ansari, 2002^29^ | Unclear | Unclear | Unclear | No | No | No | Unclear - Uncertain representativeness of adult IBD patients presenting to a specialty clinic. Excluded patients with low TPMT enzymatic activity | Fair - Unclear if TPMT testing was blinded. HWE not tested.
Gardiner, 2008^30^ | Unclear | Unclear | Unclear | No | Yes | No | Unclear - Well representative of adult IBD patients presenting to a gastroenterology clinic, but excluded patients with low TPMT enzymatic activity | Poor - HWE not tested. Sample not representative. Unclear if phenotyping influenced by genotyping results, and vice versa.
Haglund, 2004^31^ | Unclear | Unclear | Unclear | No | Yes | No | Unclear - Uncertain representativeness of adolescent and adult IBD patients. Patients were pre-selected based on their TPMT activity. | Poor - HWE not tested. Exclusion criteria not reported. Samples selected based on TPMT activity. TPMT testing not blinded.
Hindorf, 2006^32^ | Unclear | Unclear | Unclear | No | No | No | Unclear - Not representative of IBD patients, including only those currently or previously on thiopurines | Fair - HWE not reported. Unclear if genotyping was blinded.
Hindorf, 2004^33^ | Unclear | Unclear | Unclear | Unclear | Yes | No | Unclear - Not representative of adult IBD patients, including only adult IBD patients on long-term thiopurine treatment | Fair - HWE not reported. Unclear if TPMT testing was blinded.
Langley, 2002^34^ | Yes | Yes | Yes | Unclear | No | No | Unclear - Not representative of AIH patients, including only those in a tertiary care setting | Poor - HWE not reported. Unclear representativeness of sample and unclear random genotyping of a subset of patients.
Lindqvist, 2006^35^ | Unclear | Unclear | Yes | Unclear | Yes | No | Unclear - Not representative of adult IBD patients, excluding those likely to experience adverse events. | Fair - Sample not representative. Unclear if TPMT testing was blinded.
Marinaki, 2003^36^ | Unclear | Unclear | Unclear | No | No | No | Unclear - Uncertain representativeness of IBD patients. Includes only those of South Asian ancestry. | Fair - Unclear representativeness of sample. Unclear if TPMT testing was blinded.
Okada, 2005^37^ | Unclear | Unclear | Unclear | No | No | No | Unclear - Not representative of Japanese SLE patients, including only those in a tertiary care setting. | Poor - Unclear representativeness of sample. Unclear if TPMT testing was blinded and whether testing was non-selective.
Schwab, 2002^38^ | Unclear | Unclear | Unclear | No | No | No | Unclear - Not representative of IBD patients, including only those in a tertiary care setting. | Fair - Unclear representativeness of sample. Unclear if TPMT testing was blinded.
Snow, 1995^39^ | Unclear | Unclear | Unclear | No | Yes | No | Unclear - Uncertain representativeness of autoimmune dermatologic patients. No description of testing methodology. | Poor - Poorly reported testing methodology and inclusion criteria.
Stassen, 2009^40^ | Unclear | Unclear | Unclear | Unclear | No | No | Unclear - Little to no reporting of population characteristics. | Fair – Unclear if TPMT testing was blinded.
Stocco, 2005^41^ | Unclear | Unclear | Yes | No | Yes | No | Unclear - Uncertain representativeness of IBD patients. | Poor - Unclear representativeness of sample. Unclear if TPMT testing was blinded. Unclear if phenotyping influenced by genotyping results or other factors.
Stocco, 2004^42^ | Unclear | Unclear | Unclear | No | No | No | Unclear - Not representative of IBD patients, including only those in a tertiary care setting. | Poor - Unclear representativeness of sample. Unclear if TPMT testing was blinded.
von Ahsen, 2005^43^ | Unclear | Unclear | Unclear | Unclear | Yes | No | Unclear - Unrepresentative of active Crohn's disease patients. | Fair - Unclear representativeness of sample. Unclear if TPMT testing was blinded.
Winter, 2007^44^ | Unclear | Unclear | Unclear | Yes | Yes | No | Unclear - Uncertain representativeness of patients with IBD. All had previously received thiopurines | Fair - Unclear representativeness of sample. Unclear if TPMT testing was blinded.
Newman, 2010^45^ | Unclear | Unclear | Yes | No | Yes | No | Unclear - Uncertain representativeness of patients with IBD. excluded patients with important adverse events due to previous thiopurine exposure | Fair - Unclear blinded assessment, and exclusion of participants likely to experience SAE
Hindorf, 2010^46^ | Unclear | Unclear | Unclear | No | Yes | No | Little reporting of patient characteristic s. Unclear representativeness of AIH patients | Fair - Unclear blinded assessment

Abbreviations: HWE = Hardy-Weinberg equilibrium; IBD = inflammatory bowel disease; TPMT = thiopurine methyltransferase.

Table C-6 KQ1c: Diagnostic sensitivity and specificity of TPMT determinations – summary data

Study | Genotypes | Number of participants | | Genotypes | Number of participants | | Normal and hyperactivity | | Normal, hyperactivity or intermediate activity
Study | Genotypes | Normal or hyperactivity | Intermediate or low activity | Genotypes | Normal, hyperactivity or intermediate activity | Low activity | Sensitivity | Specificity | Sensitivity | Specificity
Ansari, 2008^28^ | Heterozygous or homozygous for variant(s) | 1 | 17 | Homozygous for variant(s) | 0 | 0 | 73.9 (52.8, 87.8) | 99.4 (95.9, 99.9) | 0/0 | 99.7 (96, 100)
Ansari, 2008^28^ | Non-carriers | 168 | 6 | Non-carriers or heterozygous for variant(s) | 192 | 0 | 73.9 (52.8, 87.8) | 99.4 (95.9, 99.9) | 0/0 | 99.7 (96, 100)
Ansari, 2002^29^ | Heterozygous or homozygous for variant(s) | 0 | 10 | Homozygous for variant(s) | 0 | 0 | 95.5 (55.2, 99.7) | 98.4 (78.9, 99.9) | 0/0 | 98.8 (83.3, 99.9)
Ansari, 2002^29^ | Non-carriers | 30 | 0 | Non-carriers or heterozygous for variants | 40 | 0 | 95.5 (55.2, 99.7) | 98.4 (78.9, 99.9) | 0/0 | 98.8 (83.3, 99.9)
Gardiner, 2008^30^ | Heterozygous or homozygous for variant(s) | 2 | 5 | Homozygous for variant(s) | 0 | 0 | 55.6 (25.1, 82.3) | 96.6 (87.4, 99.2) | 0/0 | 99.3 (89.5, 100)
Gardiner, 2008^30^ | Non-carriers | 57 | 4 | Non-carriers or heterozygous for variants | 68 | 0 | 55.6 (25.1, 82.3) | 96.6 (87.4, 99.2) | 0/0 | 99.3 (89.5, 100)
Haglund, 2004^31^ | Heterozygous or homozygous for variant(s) | 0 | 21 | Homozygous for variant(s) | 0 | 6 | 97.7 (72.3, 99.9) | 95 (52.5, 99.7) | 75.0 (37.7, 93.7) | 97.8 (73.2, 99.9)
Haglund, 2004^31^ | Non-carriers | 9 | 0 | Non-carriers or heterozygous for variant(s) | 22 | 2 | 97.7 (72.3, 99.9) | 95 (52.5, 99.7) | 75.0 (37.7, 93.7) | 97.8 (73.2, 99.9)
Hindorf, 2006^32^ | Heterozygous or homozygous for variant(s) | 1 | 11 | Homozygous for variant(s) | 0 | 6 | 91.7 (58.7, 98.8) | 97.5 (84.3, 99.6) | 92.9 (42.3, 99.6) | 98.9 (85.1, 99.9)
Hindorf, 2006^32^ | Non-carriers | 39 | 1 | Non-carriers or heterozygous for variant(s) | 46 | 0 | 91.7 (58.7, 98.8) | 97.5 (84.3, 99.6) | 92.9 (42.3, 99.6) | 98.9 (85.1, 99.9)
Hindorf, 2004^33^ | Heterozygous or homozygous for variant(s) | 0 | 5 | Homozygous for variant(s) | 0 | 1 | 91.7 (37.8, 99.5) | 99 (86.2, 99.9) | 100% | 99.1 (87.1, 99.9)
Hindorf, 2004^33^ | Non-carriers | 50 | 0 | Non-carriers or heterozygous for variant(s) | 54 | 0 | 91.7 (37.8, 99.5) | 99 (86.2, 99.9) | 100% | 99.1 (87.1, 99.9)
Langley, 2002^34^ | Heterozygous or homozygous for variant(s) | 4 | 6 | Homozygous for variant(s) | 0 | 0 | 66.7 (33.3, 88.9) | 90.9 (78.2, 96.5) | 0% | 99.1 (86.6, 99.9)
Langley, 2002^34^ | Non-carriers | 40 | 3 | Non-carriers or heterozygous for variant(s) | 52 | 1 | 66.7 (33.3, 88.9) | 90.9 (78.2, 96.5) | 0% | 99.1 (86.6, 99.9)
Lindqvist, 2006^35^ | Heterozygous or homozygous for variant(s) | 1 | 7 | Homozygous for variant(s) | 0 | 1 | 63.6 (33.9, 85.7) | 98 (86.9, 99.7) | 1/1 | 99.2 (88, 99.9)
Lindqvist, 2006^35^ | Non-carriers | 48 | 4 | Non-carriers or heterozygous for variant(s) | 59 | 0 | 63.6 (33.9, 85.7) | 98 (86.9, 99.7) | 1/1 | 99.2 (88, 99.9)
Marinaki, 2003^36^ | Heterozygous or homozygous for variant(s) | 0 | 5 | Homozygous for variant(s) | 0 | 0 | 91.7 (37.8, 99.5) | 99.4 (90.9, 100) | 0/0 | 99.4 (91.4, 100)
Marinaki, 2003^36^ | Non-carriers | 80 | 0 | Non-carriers or heterozygous for variant(s) | 85 | 0 | 91.7 (37.8, 99.5) | 99.4 (90.9, 100) | 0/0 | 99.4 (91.4, 100)
Okada, 2005^37^ | Heterozygous or homozygous for variant(s) | 1 | 3 | Homozygous for variant(s) | 0 | 0 | 23.1 (7.6, 52.2) | 97.6 (84.9, 99.7) | 0/0 | 99.1 (87.3, 99.9)
Okada, 2005^37^ | Non-carriers | 41 | 10 | Non-carriers or heterozygous for variant(s) | 55 | 0 | 23.1 (7.6, 52.2) | 97.6 (84.9, 99.7) | 0/0 | 99.1 (87.3, 99.9)
Schwab, 2002^38^ | Heterozygous or homozygous for variant(s) | 3 | 5 | Homozygous for variant(s) | 0 | 1 | 91.7 (37.8, 99.5) | 96.6 (90, 98.9) | 1/1 | 99.5 (92, 100)
Schwab, 2002^38^ | Non-carriers | 85 | 0 | Non-carriers or heterozygous for variant(s) | 92 | 0 | 91.7 (37.8, 99.5) | 96.6 (90, 98.9) | 1/1 | 99.5 (92, 100)
Snow, 1993^39^ | Heterozygous or homozygous for variant(s) | 0 | 5 | Homozygous for variant(s) | 0 | 0 | 91.7 (37.8, 99.5) | 97.7 (72.3, 99.9) | 0/0 | 98.1 (76.4, 99.9)
Snow, 1993^39^ | Non-carriers | 21 | 0 | Non-carriers or heterozygous for variant(s) | 26 | 0 | 91.7 (37.8, 99.5) | 97.7 (72.3, 99.9) | 0/0 | 98.1 (76.4, 99.9)
Stassen, 2009^40^ | Heterozygous or homozygous for variant(s) | 0 | 7 | Homozygous for variant(s) | 0 | 0 | 93.8 (46.1, 99.6) | 99.5 (92.7, 100) | 0/0 | 99.5 (93.1, 100)
Stassen, 2009^40^ | Non-carriers | 101 | 0 | Non-carriers or heterozygous for variant(s) | 108 | 0 | 93.8 (46.1, 99.6) | 99.5 (92.7, 100) | 0/0 | 99.5 (93.1, 100)
Stocco, 2005^41^ | Heterozygous or homozygous for variant(s) | 0 | 3 | Homozygous for variant(s) | 0 | 0 | 87.5 (26.6, 99.3) | 98.1 (75.6, 99.9) | 0/0 | 98.3 (77.7, 99.9)
Stocco, 2005^41^ | Non-carriers | 25 | 0 | Non-carriers or heterozygous for variant(s) | 28 | 0 | 87.5 (26.6, 99.3) | 98.1 (75.6, 99.9) | 0/0 | 98.3 (77.7, 99.9)
Stocco, 2004^42^ | Heterozygous or homozygous for variant(s) | 0 | 4 | Homozygous for variant(s) | 0 | 0 | 90 (32.6, 99.4) | 97.9 (74.1, 99.9) | 0/0 | 98.2 (77, 99.9)
Stocco, 2004^42^ | Non-carriers | 23 | 0 | Non-carriers or heterozygous for variant(s) | 27 | 0 | 90 (32.6, 99.4) | 97.9 (74.1, 99.9) | 0/0 | 98.2 (77, 99.9)
von Ahsen, 2005^43^ | Heterozygous or homozygous for variant(s) | 0 | 5 | Homozygous for variant(s) | 0 | 0 | 23.8 (10.3, 46) | 99 (86.2, 99.9) | 0/0 | 99.3 (89.9, 100)
von Ahsen, 2005^43^ | Non-carriers | 50 | 16 | Non-carriers or heterozygous for variant(s) | 71 | 0 | 23.8 (10.3, 46) | 99 (86.2, 99.9) | 0/0 | 99.3 (89.9, 100)
Winter, 2007^44^ | Heterozygous or homozygous for variant(s) | 0 | 11 | Homozygous for variant(s) | 0 | 0 | 64.7 (40.4, 83.2) | 99.6 (93.4, 100) | 0/0 | 99.6 (94.2, 100)
Winter, 2007^44^ | Non-carriers | 113 | 6 | Non-carriers or heterozygous for variant(s) | 129 | 1 | 64.7 (40.4, 83.2) | 99.6 (93.4, 100) | 0/0 | 99.6 (94.2, 100)
Newman, 2010^45^ | Heterozygous or homozygous for variant(s) | 0 | 35 | Homozygous for variant(s) | 0 | 1 | 94.6 (80.8, 98.6) | 99.8 (97.0, 100) | 1/1 | 99.8 (97.6, 100)
Newman, 2010^45^ | Non-carriers | 296 | 2 | Non-carriers or heterozygous for variant(s) | 332 | 0 | 94.6 (80.8, 98.6) | 99.8 (97.0, 100) | 1/1 | 99.8 (97.6, 100)
Hindorf, 2010^46^ | Heterozygous or homozygous for variant(s) | 2 | 20 | Homozygous for variant(s) | 0 | 0 | 87.0 (66.5, 95.7) | 99.0 (96.2, 99.8) | 0/0 | 99.8 (96.6, 100)
Hindorf, 2010^46^ | Non-carriers | 204 | 3 | Non-carriers or heterozygous for variant(s) | 229 | 0 | 87.0 (66.5, 95.7) | 99.0 (96.2, 99.8) | 0/0 | 99.8 (96.6, 100)

Abbreviations: TPMT = thiopurine methyltransferase.

## Key question 2 Pre-testing for TPMT status, and change in management of patients with chronic inflammatory diseases

Table C-7 KQ 2: TPMT status and change in management – characteristics and results of included study

Study | Study Design Study Region Study Setting | Inclusion and exclusion criteria | Thiopurine treatment in group that was genotyped apriori (intervention group) N=167 | Thiopurine treatment in group that was not genotyped apriori (control group) N=166 | Intervention group description | Control group description Number of participants | Results
Newman, 2010^45^ | RCT Europe Outpatient specialty clinics at 19 study centers | Inclusion: Adults with chronic inflammatory diseases, mostly IBD, eligible for azathioprine therapy Exclusion: Nursing and pregnant women and those likely to experience adverse events were excluded | AZA Mean (SD) starting dose was 0.92 (0.61) in non-carriers and 0.67 (0.35) in heterozygous carriers. There were no homozygous carriers in this group | AZA Mean (SD) starting dose 0.88 (0.54) in those later found out to be non-carriers and 0.94 (0.68) in heterozygous carriers. There was one homozygous carrier in this group | Therapy was advised to be guided by genotyping results, however, all treatment decisions were at the discretion of treating physicians | Patient management was at the discretion of the treating physician | Outcome of interest (i.e. number of patients requiring dose reduction) was not reported. However, over a 4 month period, genotyping did not significantly alter prescribing practice. Most patients in both groups were given starting doses lower than 2mg/kg/day. 7.3% of those in whom non-carrier genotype was predisclosed received AZA doses >=2mg/kg/day as compared to 8.4% of those in whom non-carrier genotype was found out after the fact. Furthermore, there was no significant difference between the two groups in terms of mean AZA prescribed dose at the end of the study period.

Table C-8 KQ 2: TPMT status and change in management – risk of bias assessment of included study, part 1

Study | Was the method of randomization appropriate? | Adequacy of allocation concealment? | Were Investigators and participants blinded to interventions? | Was there blinded assessment of outcomes? | Were groups similar at baseline? | Were outcomes described adequately? | Was there intention-to-treat analysis? | Was there a potential for financial conflict of interest?
Newman, 2010^45^ | Yes | Unclear | No | Not applicable | Yes | Yes | Yes | No

Table C-9 KQ 2: TPMT status and change in management – risk of bias assessment of included study, part 2

Was there a high loss to follow-up or important differential loss to follow-up between groups? | Was treatment adherence assessed? | Reviewers’ overall risk of bias assessment for the study | Applicability based on population characteristics and testing methodology
No | Yes | Fair – concealment of allocation is not certain, potential for selection bias | Limited applicability because there was just one homozygous carrier in the whole sample of mostly IBD patients

## Key question 3a TPMT status to guide therapy, clinical outcomes

Table C-10 KQ 3a: TPMT status to guide therapy, clinical outcomes – characteristics and results of included study

Study | Study Design Study Region Study Setting | Inclusion and exclusion criteria | Thiopurine treatment in group that was genotyped apriori (intervention group) N=167 | Thiopurine treatment in group that was not genotyped apriori (control group) N=166 | Intervention group description | Control group description | Results (n/N)
Newman, 2010^45^ | RCT Europe Outpatient specialty clinics at 19 study centers | Inclusion: Adults with chronic inflammatory diseases, mostly IBD, eligible for azathioprine therapy Exclusion: Nursing and pregnant women and those likely to experience adverse events were excluded | AZA Mean (SD) starting dose was 0.92 (0.61) in non-carriers and 0.67 (0.35) in heterozygous carriers. There were no homozygous carriers in this group | AZA Mean (SD) starting dose 0.88 (0.54) in those later found out to be non-carriers and 0.94 (0.68) in heterozygous carriers. There was one homozygous carrier in this group | Therapy was advised to be guided by genotyping results, however, all treatment decisions were at the discretion of treating physicians | Patient management was at the discretion of the treating physician | Over a 4 month duration, there were no significant differences in the outcomes of mortality (1/167 vs.3/166); SAE (4/167 vs. 8/166); and WDAE (0/167 vs. 0/166). Odds ratios of 0.33 (0.03, 3.18), 0.48 (0.14, 1.64) and non-estimibale, respectively

Table C-11 KQ 3a: TPMT status to guide therapy, clinical outcomes – Risk of bias assessment of included study, part 1

Study | Was the method of randomization appropriate? | Adequacy of allocation concealment? | Were Investigators and participants blinded to interventions? | Was there blinded assessment of outcomes? | Were groups similar at baseline? | Were outcomes described adequately? | Was there intention-to-treat analysis? | Was there a potential for financial conflict of interest?
Newman, 2010^45^ | Yes | Unclear | No | Yes for mortality and SAE, no for WDAE and other intermediate outcomes | Yes | Yes | Yes | No

Table C-12 KQ 3a: TPMT status to guide therapy, clinical outcomes – Risk of bias assessment of included study, part 2

Was there a high loss to follow-up or important differential loss to follow-up between groups? | Was treatment adherence assessed? | Reviewers’ overall risk of bias assessment for the study | Applicability based on population characteristics and testing methodology
No | Yes | Fair – Concealment of allocation is not certain, potential for selection bias | Limited applicability because there was just one homozygous carrier in the whole sample of mostly IBD patients

## Key Question 3b TPMT status to guide therapy, intermediate outcomes

Table C-13 KQ 3b: TPMT status to guide therapy, intermediate outcomes – characteristics of included studies

Study | Study Region Study Design Study Setting | Inclusion and exclusion criteria | Thiopurine treatment in group that was pre-tested for TPM status (intervention group) | Thiopurine treatment in group that was not pre-tested (control group) | Intervention group description Number of participants | Control group description Number of participants | Outcomes assessed
Newman, 2010^45^ | RCT Europe Outpatient specialty clinics at 19 study centers | Inclusion: Adults with chronic inflammatory diseases, mostly IBD, eligible for azathioprine therapy Exclusion: Nursing and pregnant women and those likely to experience adverse events were excluded | AZA Mean (SD) starting dose was 0.92 (0.61) in non-carriers and 0.67 (0.35) in heterozygous carriers. There were no homozygous carriers in this group | AZA Mean (SD) starting dose 0.88 (0.54) in those later found out to be non-carriers and 0.94 (0.68) in heterozygous carriers. There was one homozygous carrier in this group | Therapy was advised to be guided by genotyping results, however, all treatment decisions were at the discretion of treating physicians 167 | Patient management was at the discretion of the treating physician 166 | A statistically significant difference was not observed for the outcomes neutropenia (2/167 vs. 1/166); hepatitis (19/167 vs. 8/166); and pancreatitis (1/167 vs. 4/166). Odds ratios of 2 (0.18, 22.27); 2.54 (1.08, 5.97); and 0.24 (0.03, 2.21), respectively
Banerjee, 2006^47^ | Retrospective cohort North America Tertiary care academic centre | Inclusion: Diagnosis of IBD; pediatric patients (1.7–20 years, mean 14 years) | Mixed thiopurines AZA mean dose 1.7 mg/kg/day; about 10% received 6-MP dose NR Length of followup, 68 weeks | Mixed thiopurines AZA mean dose 1.2 mg/kg/day; about 10% received 6-MP dose NR Length of followup, 108 weeks | TPMT status by enzymatic activity. Normal patients given normal starting dose. Intermediate activity patients given lower starting dose. Additional dose change based on 6-TGN levels. 64 | TPMT not tested. Dose titrated based on clinical response or drug toxicity. 7 | A statistically significant difference was not observed for the outcome of leukopenia (study versus control group; 4.7 percent versus 0 percent) and hepatotoxicity (study versus control group; 9.4 percent versus 16.2 percent)

Abbreviations: 6-MP = 6-mercaptopurine; 6-TGN = 6-thioguanine nucleotide; AZA = azathioprine; IBD = inflammatory bowel disease; NR = not reported; TPMT = thiopurine methyltransferase.

Table C-14 KQ 3b: TPMT status to guide therapy – risk of bias assessment of included study, part 1

Study | Blinded participants and investigators | Blinded outcome assessment | Similarity of groups at baseline | Outcomes adequately described | Intention to treat analysis | Potential for financial conflict of interest | High loss to follow-up or differential loss to followup between groups
Newman, 2010^45^ | See Table C-10. KQ 3a above
Banerjee, 2006^47^ | Unclear | Unclear | Yes | Yes | Yes | Unlikely | No

Abbreviation: TPMT = thiopurine methyltransferase.

Table C-15 KQ 3b: TPMT status to guide therapy – risk of bias assessment of included study, part 2

Study | Adequate sample size | Avoidance of selection bias | Methods to control confounding | Appropriate TPMT test | Applicability | Summary risk of bias assessment
Banerjee, 2006^47^ | Unclear | Unclear | Unclear | Yes | Unclear - Uncertain of representativeness of pediatric IBD patients. Included on those previously treated with a stable thiopurine dose. | Poor - Only intervention group received regular metabolite monitoring with accordingly regular thiopurine adjustment -- an important unaccounted for confounding in this study that limits validity of inference drawn about the comparative effectiveness of testing from this study.

Abbreviations: IBD = inflammatory bowel disease; TPMT = thiopurine methyltransferase

## Key Question 3c Association between TPMT status and thiopurine toxicity

Table C-16 KQ 3c: Association between TPMT enzymatic activity and thiopurine toxicity – patient and study characteristics, part 1

Study | Study Region Study Setting Study Design | Inclusion and exclusion criteria | Thiopurine treatment dose (mean (range) in mg/kg/day unless otherwise noted) Concomitant treatments | TPMT activity testing method | TPMT activity range and cut- off values | Outcomes assessed
Ansari, 2002^29^ | NR Outpatient specialty clinic Cross-sectional | Inclusion: Current or past treatment with AZA. Exclusion: Reliable data on clinical response or adverse effects not obtained. | AZA (1.69 (NR)) 5-ASA, steroids | Radioassay | Low <2.5 U/mL RBC Intermediate 2.5–7.5 U/mL RBC High >7.5 U/mL RBC | Neutropenia
Czaja, 2006^48^ | Europe NR Cross-sectional | Inclusion: Diagnosis of autoimmune hepatitis; current AZA treatment | AZA (50 mg/day (median); (50–150) steroids | Radioassay | Low <6.3 U/mL RBC Intermediate 6.3–15 U/mL RBC Normal 15.1–26.4 U/mL RBC High >26.4 U/mL RBC | Withdrawal due to adverse events
Firooz, 2008^49^ | Middle East and North Africa Outpatient specialty clinic Cross-sectional | Inclusion: Current or past treatment with AZA and prednisolone. Exclusion: Reliable data on clinical response or adverse effects not available; other variants of pemphigus | AZA (NR (2–3)) steroids | High performance liquid chromatography | Low undetectable Intermediate <20 ng/mL/h RBC Normal 20–130 ng/mL/h RBC High >130 ng/mL/h RBC | Anemia, hepatitis, leukopenia, pancreatitis, withdrawal due to adverse events
Gisbert, 2006^50^ | Europe NR Prospective cohort | Inclusion: Diagnosis of IBD; adult; first time treatment with AZA | AZA (2.3 (SD: 0.5)) 5-ASA, steroids | Radioassay | Low <5 U/mL RBC Intermediate 5–13.7 U/mL RBC High >13.8 U/mL RBC | Hepatitis, myelotoxicity, pancreatitis
Hindorf, 2006^32^ | Europe NR Cross-sectional | Inclusion: Diagnosis of IBD; history of metabolite or TPMT measurements between 1997 and 2003; current or past treatment with thiopurine drugs; not yet started therapy | AZA (NR (NR)) 5-ASA, steroids | Radioassay | Low <2.5 U/mL RBC Intermediate 2.5–8.9 U/mL RBC Normal >=9.0 U/mL RBC | Hepatitis, myelotoxicity, pancreatitis
Kader, 2000^51^ | North America NR Cross-sectional | Inclusion: <21 years of age; current or past treatment with 6-MP or AZA | AZA (1.8 (1.1–2.3)); 6-MP (0.9 (0.42–1.11)) NR | NR | Low <5.0 U/mL RBC Intermediate 5.0–13.7 U/mL RBC Normal 13.8–25.1 U/mL RBC | Hepatitis, leukopenia
Lennard, 1989^52^ | Europe and North America NR Case-control | Inclusion (cases): diagnosis of autoimmune disorder; current AZA treatment; acute and prolonged immunosupression during short course (<3 months) of low-dose (<3 mg/kg) AZA. Inclusion (controls): current treatment with <3 mg/kg/day AZA for more than 6 months at unchanging dose; normal renal and hepatic function; recorded white blood cell counts above 5.0 x 109/L. Exclusion: History of myelosuppression. | AZA (Controls 1.45 (median) (1.1–2.0); Cases 1.9 (median) (1–2.6)) steroids | Radioassay | Low <5 U/mL RBC Intermediate 5–10 U/mL RBC Normal >10 U/mL RBC | Anemia, leukopenia, myelotoxicity, thrombocytopenia
Okada, 2005^37^ | Asia NR Cross-sectional | Inclusion: Diagnosis of SLE; current or past treatment with AZA | AZA (NR (NR)) NR | High performance liquid chromatography | NR | Leukopenia
Schedel, 2006^53^ | Europe NR Cohort | Inclusion: Diagnosis of chronic inflammatory disease | AZA (NR (NR)) NR | Radioassay | NR | Leukopenia, myelotoxicity,
Shah, 2008^54^ | Europe NR Cross-sectional | Inclusion: Diagnosis of IBD | AZA (NR (NR)) 5-ASA | NR | NR | Withdrawal due to adverse events
Snow, 1995^39^ | North America NR Cross-sectional | NR | AZA (NR (0.4–2.6)) None | Radioassay | Low <5 U/mL RBC Intermediate 5.0–13.7 U/mL RBC Normal 13.8–25.1 U/mL RBC | Hepatitis, leukopenia
Stassen, 2009^40^ | NR NR Chart review | NR | AZA (NR (NR)) NR | High performance liquid chromatography | Low <2.0 U/g Hb Intermediate 2–23.5 U/g Hb Normal/high >23.5 U/g Hb | Leukopenia
Stocco, 2005^41^ | Europe Outpatient specialty clinic Cross-sectional | Inclusion: Diagnosis of IBD; thiopurine treatment for at least 3 months or having experienced an adverse effect during thiopurine treatment | AZA (2.0 (median) (1–4); 6-MP (NR (NR)) 5-ASA | High performance liquid chromatography | Low <4 U/mL RBC Intermediate 4–8 U/mL RBC Normal 8–12 U/mL RBC High >12 U/mL RBC | Hepatitis, myelotoxicity, pancreatitis
Stolk, 1998^55^ | Europe Outpatient specialty clinic Non-randomized intervention study | Inclusion: Diagnosis of RA; 18–75 years of age; active disease with at least 3 of the following features: ≥ 3 swollen joints, ≥ 6 joints painful on motion or pressure, morning stiffness ≥ 45 minutes, and erythrocyte sedimentation rate, ≥ 28 mm/hour; no prior treatment with AZA. Exclusion: blood transfusion within previous 4 months; hematologic disease or abnormal hematologic parameters; kidney disease; liver disease; malignancy; acute or chronic infection; insulin-dependent diabetes mellitus; pregnancy; alcohol abuse; ACR functional class IV; use of medication that may interact with AZA or affect purine metabolism; history of poor compliance with medication regimens. | AZA (1.45 (0.6–2.9)) None | Radioassay | Low <8.3 pmol/10^6^ erythrocytes/h Intermediate 8.3–18.0 pmol/10^6^ erythrocytes/h High 18.1–39.4 pmol/10^6^ erythrocytes/h | Any infection, hepatitis, myelotoxicity
von Ahsen, 2005^43^ | Europe NR Randomized controlled trial | Inclusion: Diagnosis of active Crohn's disease; >18 years of age; prednisone treatment >300 mg during last 4 weeks or a relapse within 6 months after steroid pulse therapy. Exclusion: malignancy; pre-existing renal or hepatic disease; pregnancy or breastfeeding. | AZA (2.5 for first two weeks; subsequently two randomized groups: one remaining on 2.5, the other with 6-TGN concentration dose adjustment) 5-ASA, other | Radioassay | Low < 5 U/mL RBC Intermediate <10 U/mL RBC Normal >=10 U/mL RBC | Hepatitis, myelotoxicity, pancreatitis, withdrawal due to adverse events
Winter, 2007^44^ | Europe Outpatient specialty clinic Cross-sectional | Inclusion: Diagnosis of IBD; current or past treatment with thiopurine drugs. | AZA (1.6 (median) (NR)) 5-ASA | Mass spectrometry | Low <10 U/g Hb Intermediate 10–25 U/g Hb Normal 26–50 U/g Hb High >50 U/g Hb | Hepatitis, leucopenia, pancreatitis

Abbreviations: 5-ASA = 5-aminosalicylates; 6-MP = 6-mercaptopurine; 6-TGN = 6-thioguanine nucleotide; AZA = azathioprine; IBD = inflammatory bowel disease; NR = not reported; RA = rheumatoid arthritis; RBCs = red blood cells; SD = standard deviation; SLE = systemic lupus erythematosus; TPMT = thiopurine methyltransferase.

Table C-17 KQ 3c: Association between TPMT enzymatic activity and thiopurine toxicity – patient and study characteristics, part 2

Study | Underlying disease(s) Age group | Age (years) mean (range) (unless otherwise noted) | Females (%) | Number analyzed | Duration of observation on treatment mean (range) in months unless otherwise noted
Ansari, 2002^29^ | IBD NR | 44 | 46 | 106 | 6 (1–108)
Czaja, 2006^48^ | AIH Adults | 44 (SD 2) | 71 | 86 | 26 (1–180)
Firooz, 2008^49^ | Pemphigus vulgaris NR | 40.8 | 73.1 | 138 | NR
Gisbert, 2006^50^ | IBD Adults | 43 (SD: 14) | 50 | 394 | 38.3 (95% CI: 10.3–66.3)
Hindorf, 2006^32^ | IBD Adults | 28 (18–42) (median) | 47.2 | 364 | 18 (6–36) (median)
Kader, 2000^51^ | IBD Mixed | 13.7 (6–21) | 63.6 | 22 | 7.5 (1–24)
Lennard, 1989^52^ | Autoimmune disorders Adults | Controls: 52 (20–78) Cases: 55 (38–63) | 42.9 | 21 | Controls: 12 Cases: <3
Okada, 2005^37^ | SLE Mixed | SLE: 39.8 (14–76) Healthy volunteers 25.4 (21–57) | NR | 18 | NR
Schedel, 2006^53^ | SLE, RA, IBD, AIH and others Adults | NR | NR | 96 | NR
Shah, 2008^54^ | IBD NR | NR | NR | 131 | 19 (6–96)
Snow, 1995^39^ | Autoimmune dermatologic conditions Adults | NR (26–88) | 38.5 | 26 | NR
Stassen, 2009^40^ | Anti-neutrophil cytoplasmic antibody associated vasculitis NR | NR | NR | 108 | 47
Stocco, 2005^41^ | IBD Mixed | 14.2 (0.8–38.8) (median) | 51.4 | 28 | 19.6 (0.5–85.0)
Stolk, 1998^55^ | RA Adults | 56.2 (33–74) | 75 | 32 | 6
von Ahsen, 2005^43^ | IBD Adults | 36 (SD: 11.6) | 56.3 | 71 | 6
Winter, 2007^44^ | IBD NR | 45 | 51.4 | 130 | Adverse effects: 1.4 (median) No adverse effects: 30 (median)

Abbreviations: AIH = autoimmune hepatitis; CI = confidence interval; IBD = inflammatory bowel disease; NR = not reported; RA = rheumatoid arthritis; SD = standard deviation; SLE = systemic lupus erythematosus; TPMT = thiopurine methyltransferase.

Table C-18 KQ 3c: Association between TPMT enzymatic activity and thiopurine toxicity – risk of bias assessment, part 1

Study | Unbiased outcomes assessment and phenotyping | Similarity of groups at baseline | Outcomes adequately described | Intention to treat analysis | Potential for financial conflict of interest | High loss to follow-up or differential loss to followup between groups | Adequate sample size
Ansari, 2002^29^ | Unclear | Unclear | Yes | Yes | Unlikely | No | Unclear
Czaja, 2006^48^ | Unclear | Unclear | Yes | Yes | Unlikely | No | Unclear
Firooz, 2008^49^ | Unclear | Unclear | No | Yes | Unlikely | No | Unclear
Gisbert, 2006^50^ | Unclear | Unclear | Yes | Yes | Unlikely | No | Unclear
Hindorf, 2006^32^ | Unclear | Not similar | Yes | Unclear | Unlikely | No | Unclear
Kader, 2000^51^ | Unclear | Unclear | Yes | Yes | Unlikely | No | Unclear
Lennard, 1989^52^ | Unclear | Unclear | Yes | No | Unlikely | No | Unclear
Okada, 2005^37^ | Unclear | Unclear | Yes | Unclear | Unlikely | Unclear | Unclear
Schedel, 2006^53^ | Unclear | Unclear | No | Yes | Unlikely | Unclear | Unclear
Shah, 2008^54^ | Unclear | Unclear | Yes | Yes | Unlikely | Yes | Unclear
Snow, 1995^39^ | Unclear | Unclear | Yes | No | Unlikely | No | Unclear
Stassen, 2009^40^ | Unclear | Unclear | Unclear | Yes | Unlikely | No | Unclear
Stocco, 2005^41^ | Unclear | Unclear | Yes | No | Unlikely | Yes | Unclear
Stolk, 1998^55^ | Unclear | Unclear | No | No | Unlikely | No | Unclear
von Ahsen, 2005^43^ | Unclear | Unclear | Yes | Unclear | Likely | Yes | Unclear
Winter, 2007^44^ | Unclear | Unclear | No | No | Unlikely | No | Unclear

Abbreviations: TPMT = thiopurine methyltransferase.

Table C-19 KQ 3c: Association between TPMT enzymatic activity and thiopurine toxicity – risk of bias assessment, part 2

Study | Avoidance of selection bias | Methods to control confounding | Appropriateness of TPMT activity test | Applicability | Summary risk of bias assessment
Ansari, 2002^29^ | Unclear | No | Yes | Unclear - Uncertain representativeness of patients with IBD. | Fair – Unclear if outcome assessment is biased. Methods to control confounding not described. Avoidance of selection bias is unclear.
Czaja, 2006^48^ | Unclear | No | Yes | Unclear - Uncertain representativeness of patients with autoimmune hepatitis | Fair - Unclear if outcome assessment is biased. Avoidance of selection bias is unclear. Unclear reliability and suitability of TPMT activity assay.
Firooz, 2008^49^ | Unclear | No | Yes | Unclear - Uncertain representativeness of pemphigus vulgaris patients. Excluded patients for whom adverse event of clinical data were not available. | Fair - Unclear if outcome assessment is biased. No methods to control confounding. Unclear similarity of groups. Adequacy of sample size is unclear.
Gisbert, 2006^50^ | Unclear | Unclear | Yes | Unclear - Uncertain representativeness of patients with IBD. | Fair - Unclear if outcome assessment is biased. Methods to control confounding not described. Unclear similarity of groups.
Hindorf, 2006^32^ | Yes | No | Yes | Unclear – Uncertain representativeness of patients with IBD. Excluded patients for whom TPMT metabolite or enzymatic assessment had not been previously performed. | Fair - Unclear if outcome assessment is biased. Potential confounding by age, use of corticosteroids and 5-ASAs.
Kader, 2000^51^ | No | No | Unclear | Unclear - Uncertain representativeness of patients with IBD. | Poor - Unclear reliability and suitability of TPMT activity assay. Uncertain representativeness of pediatric patients. Unclear similarity of groups.
Lennard, 1989^52^ | No | No | Yes | Unclear - Uncertain representativeness of patients with chronic autoimmune disease. | Poor - Unclear if outcome assessment is biased. Methods to control confounding not described. Avoidance of selection bias is unclear. Unclear similarity of groups. Uncertain representativeness of autoimmune disorder patients.
Okada, 2005^37^ | Unclear | No | Yes | Unclear - Uncertain representativeness of Japanese patients with SLE. | Fair - . Avoidance of selection bias is unclear. Small sample size. Unclear if blinded outcome assessment and TPMT activity testing.
Schedel, 2006^53^ | Unclear | No | Unclear | Unclear - Uncertain representativeness of patients with chronic autoimmune disease. | Fair - Unclear if outcome assessment is biased. Avoidance of selection bias is unclear. Uncertain representativeness of patients with autoimmune disease. Unclear reliability and suitability of TPMT activity assay.
Shah, 2008^54^ | Unclear | No | Unclear | Unclear - Uncertain representativeness of patients with IBD. | Poor - No methods to control confounding. Unclear similarity of groups. Unclear reliability and suitability of TPMT activity assay. Adequacy of sample size is unclear. Unclear if blinded outcome assessment and TPMT activity testing.
Snow, 1995^39^ | No | No | Yes | Unclear – Uncertain representativeness of patients with autoimmune dermatologic conditions | Poor – Unclear similarity of groups. Small sample size. Unclear if blinded outcome assessment and TPMT activity testing. Methods to control confounding not described. Avoidance of selection bias is unclear.
Stassen, 2009^40^ | Unclear | No | Yes | Unclear – Uncertain representativeness of patients with anti-neutrophil cytoplasmic antibody associated vasculitis | Fair - Unclear if outcome assessment is biased. Unclear similarity of groups. Methods to control confounding not described.
Stocco, 2005^41^ | Unclear | No | Yes | Unclear - Uncertain representativeness of patients with IBD. | Fair - Unclear if outcome assessment is biased. Potential for selection bias.
Stolk, 1998^55^ | No | Yes | Yes | Unclear - Uncertain representativeness of patients with rheumatoid arthritis. Strict inclusion criteria. | Fair - Unclear if outcome assessment is biased. Avoidance of selection bias is unclear. Small sample size.
von Ahsen, 2005^43^ | Unclear | No | Yes | Unclear - Uncertain representativeness of patients with IBD. Excluded those likely to experience adverse events. | Fair – Avoidance of selection bias is unclear. Uncertain representativeness of adult IBD patients. Unclear if blinded outcome assessment and TPMT activity testing. Potential for selective outcome reporting bias.
Winter, 2007^44^ | Unclear | No | Yes | Unclear - Uncertain representativeness of patients with IBD. Included only those patients with a history of thiopurine use. | Fair - Unclear if outcome assessment is biased. Unclear similarity of groups.

Abbreviations: 5-ASA = 5-aminosalicylates; IBD = inflammatory bowel disease; SLE = systemic lupus erythematosus; TPMT = thiopurine methyltransferase.

Table C-20 KQ 3c: Association between TPMT enzymatic activity and thiopurine toxicity – summary data

Study | Outcomes and definition | Low activity | | Intermediate activity | | Normal activity | | Intermediate vs. normal | Low vs. intermediate | Low vs. normal
Study | Outcomes and definition | n with events | n without events | n with events | n without events | n with events | n without events | Odds ratio (95% CI)
Ansari, 2002^29^ | Neutropenia Neutrophil count <2.0 X 10^9^ cells | 0 | 0 | 1 | 9 | 1 | 95 | 10.56 (0.61, 183.38)
Czaja, 2006^48^ | WDAE Included a range of side effects (thrombocytopenia, leukopenia, pancytopenia, nausea and vomiting, malaise and opportunistic infection) that treating physician deemed severe enough to end treatment | 0 | 1 | 2 | 10 | 9 | 64 | 1.42 (0.27, 7.56) | 1.4 (0.04, 45.68) | 2.26 (0.09, 59.69)
Firooz, 2008^49^ | WDAE NR | 0 | 0 | 1 | 10 | 13 | 114 | 0.88 (0.1, 7.41)
Firooz, 2008^49^ | Hepatitis >3 fold increase of the upper limit of normal liver enzymes after 10 days | 0 | 0 | 1 | 10 | 10 | 117 | 1.17 (0.14, 10.09)
Firooz, 2008^49^ | Pancreatitis NR | 0 | 0 | 0 | 11 | 1 | 126 | 3.67 (0.14, 95.24)
Firooz, 2008^49^ | Leukopenia NR | 0 | 0 | 0 | 11 | 1 | 126 | 3.67 (0.14, 95.24)
Firooz, 2008^49^ | Anemia NR | 0 | 0 | 0 | 11 | 1 | 126 | 3.67 (0.14, 95.24)
Gisbert, 2006^50^ | Pancreatitis Abdominal pain present and serum amylase >3 times upper normal limit | 0 | 0 | 0 | 28 | 11 | 355 | 0.54 (0.03, 9.44)
Gisbert, 2006^50^ | Myelotoxicity NR | 0 | 0 | 4 | 24 | 13 | 353 | 4.53 (1.37, 14.94)
Gisbert, 2006^50^ | Hepatitis Transaminases two times higher than normal values | 0 | 0 | 0 | 0 | 4 | 362
Hindorf, 2006^32^ | Hepatitis Included all types of hepatotoxic reactions | 0 | 6 | 4 | 41 | 15 | 298 | 1.94 (0.61, 6.12) | 0.71 (0.03, 14.78) | 1.48 (0.08, 27.51)
Hindorf, 2006^32^ | Pancreatitis NR | 0 | 6 | 2 | 43 | 13 | 300 | 1.07 (0.23, 4.92) | 1.34 (0.06, 31.12) | 1.71 (0.09, 31.99)
Hindorf, 2006^32^ | Myelotoxicity Included all types of haematological toxicity (anemia, leukopenia, neutropenia, thrombocytopenia) | 3 | 3 | 3 | 42 | 22 | 291 | 0.94 (0.27, 3.29) | 14 (1.93, 101.72) | 13.23 (2.52, 69.43)
Kader, 2000^51^ | Leukopenia WBC <4000/mm^3^ | 0 | 0 | 1 | 1 | 1 | 19 | 19 (0.62, 583.42)
Kader, 2000^51^ | Hepatitis Aminotransferases >2 times normal | 0 | 0 | 1 | 1 | 2 | 18 | 9 (0.39, 206.54)
Lennard, 1989^52^ | Leukopenia NR | 4 | 1 | 0 | 5 | 0 | 11 | | 33 (1.06, 1023.62) | 69 (2.35, 2028.86 )
Lennard, 1989^52^ | Thrombocytopenia NR | 3 | 2 | 0 | 5 | 0 | 11 | | 15.4 (0.56, 425.55) | 32.2 (1.23, 841.87)
Lennard, 1989^52^ | Anemia NR | 4 | 1 | 0 | 5 | 0 | 11 | | 33 (1.06, 1023.62) | 69 (2.35, 2028.86 )
Lennard, 1989^52^ | Myelotoxicity NR | 3 | 2 | 0 | 5 | 0 | 11 | | 15.4 (0.56, 425.55) | 32.2 (1.23, 841.87)
Okada, 2005^37^ | Leukopenia WBC <2300/mm^3^ | 0 | 0 | 1 | 2 | 2 | 13 | 3.25 (0.19, 54.78)
Schedel, 2006^53^ | Myelotoxicity Pancytopenia (not defined) | 0 | 3 | 1 | 27 | 1 | 64 | 2.37 (0.14, 39.3) | 2.62 (0.09, 77.58) | 6.14 (0.21, 179.81)
Schedel, 2006^53^ | Leukopenia NR | 2 | 1 | 2 | 26 | 0 | 65 | 12.36 (0.57, 266.16) | 26 (1.58, 426.87) | 218.33 (6.99, 6815.05 )
Shah, 2008^54^ | WDAE NR | NR | NR | 1 | 11 | 18 | 101 | 0.51 (0.06, 4.2)
Snow, 1995^39^ | Hepatitis Raised aspartate transaminase and alanine transaminase | 0 | 0 | 0 | 5 | 1 | 20 | 1.24 (0.04, 34.93)
Snow, 1995^39^ | Leukopenia NR | 0 | 0 | 2 | 3 | 1 | 20 | 13.33 (0.91, 196.38)
Stassen, 2009^40^ | Leukopenia NR | 0 | 0 | 3 | 4 | 34 | 67 | 1.48 (0.31, 6.98)
Stassen, 2009^40^ | Thrombocytopenia NR | 0 | 0 | 0 | 7 | 8 | 93 | 0.73 (0.04, 13.98)
Stassen, 2009^40^ | Anemia NR | 0 | 0 | 3 | 4 | 30 | 71 | 1.78 (0.37, 8.42)
Stocco, 2005^41^ | Hepatitis Alanine aminotransferase, gamma-glutamyl transferase or alkaline phosphatase >2 times normal levels | 0 | 0 | 0 | 3 | 0 | 25
Stocco, 2005^41^ | Pancreatitis Severe abdominal pain accompanied by serum amylase level >2 times normal levels | 0 | 0 | 0 | 3 | 1 | 24 | 2.33 (0.08, 69.29)
Stocco, 2005^41^ | Myelotoxicity Leukopenia (WBC <3000/mm^3^) and/or thrombocytopenia (platelets <100,000/mm^3^) | 0 | 0 | 0 | 3 | 3 | 22 | 0.92 (0.04, 21.86)
Stolk, 1998^55^ | Any infection Upper airway infection | 0 | 0 | 1 | 7 | 0 | 24 | 9.8 (0.36, 266.64)
Stolk, 1998^55^ | Hepatitis NR | 0 | 0 | 1 | 7 | 1 | 23 | 3.29 (0.18, 59.6)
Stolk, 1998^55^ | Myelotoxicity Pancytopenia | 0 | 0 | 0 | 8 | 1 | 23 | 0.92 (0.03, 24.87)
von Ahsen, 2005^43^ | WDAE Withdrawal from study for whatever reason | 0 | 0 | 14 | 7 | 18 | 32 | 3.56 (1.21, 10.42)
von Ahsen, 2005^43^ | Hepatitis Aspartate or alanine aminotransferase >=2 times upper limit of reference interval | 0 | 0 | 1 | 20 | 2 | 48 | 1.2 (0.1, 14)
von Ahsen, 2005^43^ | Pancreatitis Upper abdominal pain accompanied by pancreatic amylase or lipase >=2 times upper limit of reference interval | 0 | 0 | 1 | 20 | 1 | 49 | 2.45 (0.15, 41.11)
von Ahsen, 2005^43^ | Myelotoxicity Myelosuppression (leukocyte count <2.5x10^9^/L or platelet count <100x10^9^/L) | 0 | 0 | 0 | 21 | 0 | 40
Winter, 2007^44^ | Hepatitis Deranged liver function tests | 0 | 1 | 1 | 15 | 8 | 105 | 0.88 (0.1, 7.5) | 3.44 (0.09, 127.7) | 4.14 (0.16, 109.52)
Winter, 2007^44^ | Pancreatitis NR | 0 | 1 | 1 | 15 | 0 | 113 | 21.97 (0.86, 563.38) | 3.44 (0.09, 127.7)
Winter, 2007^44^ | Leukopenia Mild leukopenia (WBC 2–3 x10^9^/L) and severe leukopenia (WBC < 2 x10^9^/L) | 1 | 0 | 1 | 15 | 8 | 105 | 0.88 (0.1, 7.5) | 31 (0.84, 1149.3) | 37.24 (1.41, 985.68)

Abbreviations: CI = confidence interval; n = number; NR = not reported; WBC = white blood cell count; WDAE = withdrawal due to adverse events

Table C-21 KQ 3c: Association between TPMT genotype and thiopurine toxicity – patient and study characteristics, part 1

Study | Study region Study setting Study design | Inclusion and exclusion criteria | Thiopurine treatment dose (mean (range) in mg/kg/day unless otherwise noted) Concomitant treatments | Genotyping method | SNPs genotyped | Outcomes assessed
Ansari, 2008^28^ | Europe NR Non-randomized intervention study | Inclusion: Diagnosis of IBD; 18–80 years of age. Exclusion: Past thiopurine treatment; history of use of biologics; very low TPMT activity (<10 pmol/h/mg Hb). | AZA (2.0 (1.9–2.4) (median)) 5-ASA, steroids | NR | TPMT*3A, *3B, *3C | Hepatitis, leukopenia, pancreatitis, withdrawal due to adverse events
Bezier, 2008^56^ | Europe Inpatient Cross-sectional | Inclusion: Diagnosis of bullous pemphigoid, cicatrical pemphigoid, pemphigus or epidermolysis bullosa acquista; hospitalized in a Dermatology department; history of TPMT genotyping. Exclusion: IgA bullous dermatosis linear; dermatosis herpetiformis; pemphigoid gestationis. | AZA (2.2 (NR)) steroids, others | Polymerase chain reaction | TPMT*2, *3A, *3B, *3C | Anemia, any infection, leukopenia, neutropenia, withdrawal due to adverse events
Black, 1998^57^ | Europe Outpatient specialty clinic Prospective cohort | Inclusion: Current or past AZA treatment | AZA (NR (2–3)) NSAIDs | Polymerase chain reaction | TPMT*2, *3A | Hepatitis, leukopenia
Corominas, 2003^58^ | Europe Outpatient specialty clinic Cross-sectional | Inclusion: Diagnosis of rheumatoid arthritis; current treatment with low-dose AZA | AZA (NR (0.5–1.5)) NR | Polymerase chain reaction | TPMT*2, *3A, *3B, *3C, *7, *8 | Withdrawal due to adverse events
De Ridder, 2006^59^ | Europe NR Cross-sectional | Inclusion: Diagnosis of pediatric-onset IBD; current or past AZA treatment of at least 3 months unless stopped due to adverse effects; <19 years of age | AZA (NR (2–2.5)) NR | Polymerase chain reaction | TPMT*2, *3A, *3B, *3C | Hepatitis, leukopenia, pancreatitis
Derijks, 2004^60^ | Europe Outpatient specialty clinic Non-randomized intervention study | Inclusion: Diagnosis of IBD; 18–75 years of age; 6-MP indicated due to steroid tolerance, steroid resistance, or AZA intolerance. Exclusion: Pregnancy or expected pregnancy within 6 months; inadequate contraception in women; lactation; active infection; history of tuberculosis; HIV; hepatitis B or C; severe pancreatitis; malignancy; current treatment with other immunosuppressive drugs; impaired renal function; elevated liver function tests; bone marrow suppression. | 6-MP (50 mg/day (NR)) 5-ASA | Polymerase chain reaction | TPMT*2, *3A, *3B, *3C | Hepatitis, leukopenia, pancreatitis
Dubinsky, 2000^61^ | North America Outpatient specialty clinic Prospective cohort | Exclusion: Leukopenia; increased serum hepatic or pancreatic enzyme activity | AZA (NR (NR)), 6-MP (1.25 (0.4–2.4)) 5-ASA | Polymerase chain reaction | TPMT*3A, *3B, *3C | Leukopenia
Gearry, 2004^62^ | Oceania Outpatient specialty clinic Case-control | Inclusion: Past treatment with thiopurine drugs | Mixed thiopurines NR | Polymerase chain reaction | TPMT*1, *2, *3A, *3C | Hepatitis, leukopenia, pancreatitis
Hibi, 2003^63^ | Asia Outpatient specialty clinic Cross-sectional | Inclusion: Diagnosis of IBD; past AZA or 6-MP treatment | AZA (NR (25–100 mg/day)), 6-MP (NR (30–50 mg/day) NR | Polymerase chain reaction | TPMT*2, *3B, *3A, *3C | Leukopenia
Hindorf, 2006^32^ | Europe NR Cross-sectional | Inclusion: Diagnosis of IBD; history of metabolite or TPMT measurements; current or past treatment with thiopurine drugs. Exclusion: Patients who had not yet started therapy | AZA (NR (NR)) 5-ASA, steroids | Pyrosequencing | TPMT*2, *3A, *3B, *3C, *3D, *4, *5, *6, *7, *8, *10, *14, *15 | Hepatitis, myelotoxicity, pancreatitis
Ishioka, 1999^64^ | Asia NR Unclear if prospective or retrospective design | Included: Diagnosis of a rheumatic disease; past AZA treatment; Japanese | AZA (50 mg/day (NR)) NR | Polymerase chain reaction | TPMT*1, *2, *3A, *3B, *3C | Leukopenia
Jae Hak, 2008^65^ | Asia Outpatient specialty clinic Case-control | Inclusion: Diagnosis of IBD; current or past thiopurine treatment for at least 6 months | AZA (NR (NR)), 6-MP (NR (NR)) NR | High performance liquid chromatography | TPMT*1, *2, *3A, *3B, *3C | Leukopenia
Joji, 2003^66^ | Europe NR Prospective cohort | NR | AZA (NR (NR)) 5-ASA | Polymerase chain reaction | TPMT*1, *2, *3A, *3B, *3C | Leukopenia, myelotoxicity
Jun, 2005^67^ | Asia NR Cross-sectional | Inclusion: Diagnosis of SLE; Korean | AZA (22.1 mg/day (NR)) NR | Polymerase chain reaction | TPMT*2, *3A, *3B, *3C, *3D, *6 | Hepatitis, leukopenia
Lopez, 2006^68^ | NR NR Case-control | NR | AZA (NR (NR)) NR | NR | TPMT*2, *3A, *3B, *3C, *3D | Pancreatitis
Marinaki, 2004^69^ | Europe Outpatient specialty clinic Case-control | Cases: Diagnosis of IBD; Caucasian; history of AZA- related adverse events. Controls: Caucasian; past AZA treatment for at least 3 months without adverse events. | AZA (Cases 1.81 (0.39–2.59) Controls 1.92 (0.91–3.26)) 5-ASA, steroids, others | Polymerase chain reaction | TPMT*2, *3A, *3C | Hepatitis, neutropenia, pancreatitis
Okada, 2005^37^ | Asia NR Cross-sectional | Inclusion: Diagnosis of SLE | AZA (NR (NR)) NR | Polymerase chain reaction | TPMT*2, *3A, *3B, *3C | Leukopenia
Palmieri, 2007^70^ | Europe NR Prospective cohort | Inclusion: Diagnosis of IBD; 21–58 years; current AZA or 6-MP treatment. Exclusion: Past AZA or 6-MP treatment of less than 6 months; no history of adverse events. | AZA (NR (2–2.5)), 6-MP (NR (1–1.25)) 5-ASA | Polymerase chain reaction | TPMT*3A, *3B, *3C | Hepatitis, leukopenia, pancreatitis
Reuther, 2003^71^ | Europe Outpatient specialty clinic Cross-sectional | Inclusion: Diagnosis of Crohn's disease; current AZA maintenance treatment; no history of adverse effects | AZA (1.57 (0.58–2.24)) 5-ASA, steroids | Polymerase chain reaction | TPMT*3A, *3B, *3C | Hepatitis, leukopenia
Schmeling, 2007^72^ | NR NR Cross-sectional | Inclusion: Diagnosis of SLE; current AZA treatment; pediatric | AZA (NR (NR)) NR | NR | TPMT*2, *3A, *3B, *3C | Hepatitis, leukopenia
Seddik, 2003^73^ | NR NR Prospective cohort | NR | AZA (NR (100–200mg/day)), 6-MP (NR (50–100mg/day)) NR | Polymerase chain reaction | TPMT*2, *3A, *3B, *3C | Leukopenia
Snow, 1995^39^ | North America NR Cross-sectional | NR | AZA (NR (0.4–2.6)) NR | NR | NR | Hepatitis, leukopenia
Stassen, 2009^40^ | NR NR Chart review | NR | AZA (NR (NR)) NR | Polymerase chain reaction | TPMT*2, *3A, *3B, *3C | Anemia, leukopenia, thrombocytopenia
Stocco, 2007^74^ | Europe Outpatient specialty clinic Cross-sectional | Inclusion: Diagnosis of IBD; current AZA treatment | AZA (2 (1–5)) NR | Polymerase chain reaction | TPMT*2, *3A, *3B, *3C | Any infection, hepatitis, myelotoxicity, pancreatitis
Stocco, 2005^41^ | Europe Outpatient specialty clinic Cross-sectional | Inclusion: Diagnosis of IBD; past thiopurine treatment for at least 3 months or having experienced an adverse effect during thiopurine treatment | AZA (2.0 (1–4) (median)); 6-MP (NR (NR)) NR | Polymerase chain reaction | TPMT*2, *3A, *3B, *3C | Hepatitis, myelotoxicity, pancreatitis
Stocco, 2004^42^ | Europe Outpatient specialty clinic Cross-sectional | Inclusion: Diagnosis of IBD; current AZA treatment | AZA (2 (1–3) (median)) NR | Polymerase chain reaction | TPMT*2, *3A, *3B, *3C | Hepatitis, leukopenia, pancreatitis, thrombocytopenia
Tamori, 2007^75^ | Asia NR Cross-sectional | Inclusion: Diagnosis of AIH; Japanese | AZA (50 (NR)) NR | Polymerase chain reaction | TPMT*2, *3A, *3B, *3C | Myelotoxicity
Tani, 2009^76^ | Europe NR Cross-sectional | Included: Diagnosis of rheumatic disease; current AZA treatment; Italian; Caucasian | AZA (1.42 (0.5–2)) 5-ASA, steroids, others | Polymerase chain reaction | TPMT*2, *3A, *3B, *3C | Any infection, leukopenia, thrombocytopenia, withdrawal due to adverse events
van Dieren, 2005^77^ | NR NR Prospective cohort | Inclusion: Diagnosis of IBD; first AZA treatment between January 2003 and November 2004 | AZA (NR (NR)) NR | Polymerase chain reaction | NR | Hepatitis, leukopenia, thrombocytopenia
von Ahsen, 2005^43^ | Europe NR Randomized controlled trial | Inclusion: Diagnosis of active Crohn's disease; >18 years of age; prednisone treatment >300 mg during last 4 weeks or relapse within 6 months after steroid pulse therapy. Exclusion: History of cancer; preexisting renal or hepatic disease; pregnant; breast feeding. | AZA (2.5 for first two weeks; subsequently two randomized groups: one remaining on 2.5, the other with 6-TGN concentration dose adjustment) 5-ASA, others | Polymerase chain reaction | TPMT*2, *3A, *3B, *3C | Hepatitis, myelotoxicity, pancreatitis
Winter, 2007^44^ | Europe Outpatient specialty clinic Cross-sectional | Inclusion: Diagnosis of IBD; current or past treatment with thiopurine drugs | AZA (1.6 (NR) (median)) 5-ASA | Polymerase chain reaction | TPMT*2, *3A, *3B, * 3C | Hepatitis, leukopenia, pancreatitis,
Zelinkova, 2006^78^ | Europe Outpatient specialty clinic Cross-sectional | Inclusion: Diagnosis of IBD; past AZA treatment; reliable data available on AZA use and related side effects | AZA (132 (50–250) mg/day) 5-ASA, steroids | Polymerase chain reaction | TPMT*1, *2, *3A, *3B, *3C | Hepatitis, leukopenia
Newman, 2010^45^ | Europe Outpatient specialty clinic Prospective Cohort | Nursing and pregnant women and those likely to experience adverse events were excluded | AZA (on average approx. 1mg/kg/day) | Polymerase chain reaction | TPMT *2, *3A, *3B, *3C | Mortality, WDAE, SAE, hepatitis, pancreatitis, and neutropenia
Kolorz 2009^79^ | Europe NR Cross-sectional | NR | AZA, Dosage NR | Polymerase chain reaction | TPMT *2, *3A, *3B, *3C | Leukopenia

Abbreviations: 5-ASA = 5-aminosalicylates; 6-MP = 6-mercaptopurine; AIH = autoimmune hepatitis; AZA = azathioprine; HIV = human immunodeficiency virus; IBD = inflammatory bowel disease; NR = not reported; NSAID = Non-steroidal anti-inflammatory drug; SLE = systemic lupus erythematosus; SNP = single nucleotide polymorphism; TPMT = thiopurine methyltransferase; WDAE = withdrawal due to adverse events; SAE = serious adverse events;

Table C-22 KQ 3c: Association between TPMT genotype and thiopurine toxicity – patient and study characteristics, part 2

Study | Underlying disease(s) Age group | Age (years) mean (range) (unless otherwise noted) | Females (%) | Number analyzed | Duration of observation on treatment mean (range) in months unless otherwise noted
Ansari, 2002^29^ | IBD NR | 44 | 46 | 106 | 6 (1–108)
Czaja, 2006^48^ | AIH Adults | 44 (SD 2) | 71 | 86 | 26 (1–180)
Firooz, 2008^49^ | Pemphigus vulgaris NR | 40.8 | 73.1 | 138 | NR
Gisbert, 2006^50^ | IBD Adults | 43 (SD: 14) | 50 | 394 | 38.3 (95% CI: 10.3–66.3)
Hindorf, 2006^32^ | IBD Adults | 28 (18–42) (median) | 47.2 | 364 | 18 (6–36) (median)
Kader, 2000^51^ | IBD Mixed | 13.7 (6–21) | 63.6 | 22 | 7.5 (1–24)
Lennard, 1989^52^ | Autoimmune disorders Adults | Controls: 52 (20–78) Cases: 55 (38–63) | 42.9 | 21 | Controls: 12 Cases: <3
Okada, 2005^37^ | SLE Mixed | SLE: 39.8 (14–76) Healthy volunteers 25.4 (21–57) | NR | 18 | NR
Schedel, 2006^53^ | SLE, RA, IBD, AIH and others Adults | NR | NR | 96 | NR
Shah, 2008^54^ | IBD NR | NR | NR | 131 | 19 (6–96)
Snow, 1995^39^ | Autoimmune dermatologic conditions Adults | NR (26–88) | 38.5 | 26 | NR
Stassen, 2009^40^ | Anti-neutrophil cytoplasmic antibody associated vasculitis NR | NR | NR | 108 | 47
Stocco, 2005^41^ | IBD Mixed | 14.2 (0.8–38.8) (median) | 51.4 | 28 | 19.6 (0.5–85.0)
Stolk, 1998^55^ | RA Adults | 56.2 (33–74) | 75 | 32 | 6
von Ahsen, 2005^43^ | IBD Adults | 36 (SD: 11.6) | 56.3 | 71 | 6
Winter, 2007^44^ | IBD NR | 45 | 51.4 | 130 | Adverse effects: 1.4 (median) No adverse effects: 30 (median)
Newman, 2010^45^ | Majority IBD patients | 43 | 50.6 | 166 | 4
Kolorz 2009^79^ | IBD | 35 | 41 | 87 | NR

Abbreviations: AIH = autoimmune hepatitis; CI = confidence interval; IBD = inflammatory bowel disease; NR = not reported; RA = rheumatoid arthritis; SD = standard deviation; SLE = systemic lupus erythematosus; TPMT = thiopurine methyltransferase.

Table C-23 KQ 3c: Association between TPMT genotype and thiopurine toxicity – risk of bias assessment, part 1

Study | Comparable genotype groups | Participants enrolled without prior knowledge of genotype | Unbiased outcome and genotype assessment | Clear genotyping method description | Reliable genotyping method | Reported ambiguous results due to genotyping error | HWE tested
Ansari, 2008^28^ | Unclear | Yes | Yes | No | Unclear | No | Yes
Bezier, 2008^56^ | Unclear | Yes | Unclear | Yes | Yes | No | No
Black, 1998^57^ | Unclear | Yes | Yes | Yes | Yes | Unclear | No
Corominas, 2003^58^ | Unclear | Yes | Unclear | Yes | Unclear | Unclear | No
De Ridder, 2006^59^ | Unclear | Yes | Unclear | No | No | No | No
Derijks, 2004^60^ | Unclear | Yes | Unclear | Yes | Yes | Yes | No
Dubinsky, 2000^61^ | Unclear | Yes | Yes | Yes | Unclear | No | No
Gearry, 2004^62^ | Unclear | Yes | Unclear | Yes | Unclear | No | No
Hibi, 2003^63^ | Unclear | Yes | Unclear | Yes | Yes | No | No
Hindorf, 2006^32^ | Unclear | Unclear | Unclear | Unclear | Unclear | No | No
Ishioka, 1999^64^ | Unclear | Unclear | Unclear | Yes | No | No | No
Jae Hak, 2008^65^ | Unclear | Unclear | Unclear | No | Unclear | No | No
Joji, 2003^66^ | Unclear | Yes | Unclear | Yes | Unclear | No | No
Jun, 2005^67^ | Unclear | Yes | Unclear | Yes | Unclear | No | No
Lopez, 2006^68^ | Unclear | Unclear | Unclear | No | No | No | No
Marinaki, 2004^69^ | Unclear | Yes | Unclear | No | No | No | No
Okada, 2005^37^ | Unclear | Yes | Unclear | Yes | Yes | No | No
Palmieri, 2007^70^ | Yes | Yes | Unclear | Yes | Unclear | No | Yes
Reuther, 2003^71^ | Unclear | Yes | Unclear | No | No | Yes | No
Schmeling, 2007^72^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear
Seddik, 2003^73^ | Unclear | Unclear | Unclear | No | Unclear | No | No
Snow, 1995^39^ | Unclear | Unclear | Unclear | No | Unclear | No | No
Stassen, 2009^40^ | Unclear | Yes | Unclear | Yes | Unclear | No | No
Stocco, 2007^74^ | Unclear | Yes | Unclear | Yes | No | No | No
Stocco, 2005^41^ | Unclear | Yes | Unclear | No | Unclear | No | No
Stocco, 2004^42^ | Unclear | Yes | Yes | Yes | Unclear | Unclear | No
Tamori, 2007^75^ | Unclear | Yes | Unclear | Yes | Unclear | Unclear | No
Tani, 2009^76^ | Unclear | Yes | Unclear | Yes | No | No | No
van Dieren, 2005^77^ | Unclear | Yes | Unclear | No | Unclear | No | No
von Ahsen, 2005^43^ | Unclear | Yes | Unclear | Yes | Yes | No | No
Winter, 2007^44^ | Unclear | Yes | Unclear | Yes | Unclear | No | No
Zelinkova, 2006^78^ | Unclear | Yes | Unclear | Yes | Unclear | No | No
Newman, 2010^45^ | Unclear | Yes | Yes | Yes | Unclear | No | No
Kolorz 2009^79^ | Unclear | Yes | Unclear | Yes | Unclear | No | No

Abbreviations: HWE = Hardy-Weinberg equilibrium; TPMT = thiopurine methyltransferase.

Table C-24 KQ 3c: Association between TPMT genotype and thiopurine toxicity – risk of bias assessment, part 2

Study | Assessed gene-gene interaction | Assessed compliance with thiopurine treatment (and corrected differences as required) | Consistent DNA source for all patients | Reported loss to followup | Potential for survival bias | Potential for financial conflict of interest | Applicability | Summary risk of bias assessment
Ansari, 2008^28^ | No | No | Yes | Yes | No | No | Applicable | Fair - Methods to control confounding not described. Genotyping method unclear.
Bezier, 2008^56^ | No | No | Yes | Yes | No | No | Unclear – Uncertain representativeness of patients with autoimmune bullous diseases. Included only hospitalized severe cases. | Fair – HWE not reported. Compliance not clear. Unclear similarity of groups. Unclear if blinded outcome or genotype assessment.
Black, 1998^57^ | No | Yes | Yes | Yes | No | Unclear | Unclear - Uncertain representativeness of patients with several rheumatic diseases. | Fair – HWE not reported.
Corominas, 2003^58^ | Unclear | No | Yes | Yes | Unclear | Unclear | Applicable | Fair - HWE not reported. Methods to control confounding not described. Unclear if blinded outcome or genotype assessment.
De Ridder, 2006^59^ | No | No | Yes | No | No | No | Unclear - Uncertain representativeness of pediatric patients with IBD. | Fair - Avoidance of selection bias is unclear. Unclear if blinded outcome or genotype assessment. Inadequate description of genotyping method. Compliance not clear.
Derijks, 2004^60^ | No | No | Yes | No | No | Unclear | Unclear - Uncertain representativeness of patients with IBD. Strict eligibility criteria. | Fair – Potential selection bias. Unclear if blinded outcome or genotype assessment.
Dubinsky, 2000^61^ | No | No | Yes | Yes | No | Yes | Not applicable – Not representative of children with IBD. Excluded children with leukopenia and increased hepatic or pancreatic enzymes before treatment initiation. | Fair – HWE not reported. Unclear similarity of groups. Unclear reliability of genotyping method.
Gearry, 2004^62^ | No | No | Yes | No | No | No | Unclear - Uncertain representativeness of patients with IBD. | Fair – Avoidance of selection bias is unclear. Unclear similarity of groups. Unclear if blinded outcome or genotype assessment.
Hibi, 2003^63^ | No | No | Yes | Yes | No | No | Unclear - Uncertain representativeness of patients with IBD. | Fair - Potential selection bias. Unclear if blinded outcome or genotype assessment.
Hindorf, 2006^32^ | Unclear | No | Unclear | Yes | Unclear | No | Unclear - Unclear representativeness of patients with IBD population. Included only patients with history of TPMT metabolite or enzymatic assay testing. | Fair - Inadequate description of genotyping method. Unclear reliability of genotyping method. Unclear similarity of groups. Methods to control confounding not described.
Ishioka, 1999^64^ | No | No | Yes | Yes | No | No | Unclear – Unclear representativeness of Japanese patients with rheumatic diseases. | Fair - HWE not reported. Unclear similarity of groups. Unclear if blinded outcome or genotype assessment. Unclear reliability of genotyping method.
Jae Hak, 2008^65^ | No | No | Unclear | No | Unclear | No | Unclear - Uncertain representativeness of patients with IBD. | Fair - HWE not reported. Unclear if blinded outcome or genotype assessment. Unclear similarity of groups.
Joji, 2003^66^ | No | No | Yes | No | No | Unclear | Unclear - Uncertain representativeness of patients with IBD. | Fair - HWE not reported. Unclear if blinded outcome or genotype assessment. Unclear similarity of groups.
Jun, 2005^67^ | No | No | Yes | No | No | No | Unclear - Unclear representativeness of Korean patients with SLE. | Fair – Avoidance of selection bias is unclear. Unclear if blinded outcome or genotype assessment.
Lopez, 2006^68^ | No | No | Unclear | No | Unclear | Unclear | Unclear - Uncertain representativeness of patients with IBD. | Poor - Poor reporting of quality items (only abstract available)
Marinaki, 2004^69^ | Yes | No | Yes | No | No | No | Unclear - Uncertain representativeness of patients with IBD. | Fair - Avoidance of selection bias is unclear. Unclear if blinded outcome or genotype assessment. Inadequate description of genotyping method.
Okada, 2005^37^ | No | No | Yes | No | Unclear | Unclear | Unclear - Uncertain representativeness of Japanese patients with SLE. | Fair - Avoidance of selection bias is unclear. Small sample size. Unclear if blinded outcome or genotype assessment.
Palmieri, 2007^70^ | No | No | Yes | No | No | No | Applicable | Fair - Compliance not clear. Unclear if blinded outcome or genotype assessment. Unclear reliability of genotyping method.
Reuther, 2003^71^ | No | No | Yes | Yes | No | No | Unclear - Uncertain representativeness of patients with Crohn's disease. | Fair - Avoidance of selection bias is unclear. Inadequate description of genotyping method.
Schmeling, 2007^72^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Poor - Poor reporting of risk of bias items (only abstract available)
Seddik, 2003^73^ | No | No | Unclear | No | Unclear | Unclear | Unclear - Uncertain representativeness of patients with IBD. | Poor - Poor reporting of risk of bias items (only abstract available)
Snow, 1995^39^ | No | No | Unclear | Yes | No | Unclear | Unclear - Uncertain representativeness of patients with autoimmune dermatologic conditions. | Poor - Unclear if blinded outcome or genotype assessment. Inadequate description of genotyping method. Unclear reliability of genotyping method. HWE not reported.
Stassen, 2009^40^ | No | Unclear | Yes | No | Unclear | No | Unclear – Unclear representativeness of patients with anti- neutrophil cytoplasmic antibody associated vasculitis | Fair - HWE not reported. Unclear if blinded outcome or genotype assessment. Unclear similarity of groups. Unclear if genotype was determined prospectively or retrospectively.
Stocco, 2007^74^ | No | No | Yes | No | No | No | Unclear - Uncertain representativeness of patients with IBD. | Fair – Unclear if blinded outcome or genotype assessment. Inadequate description of genotyping method. Unclear reliability of genotyping method. HWE not reported. Incomplete outcomes data.
Stocco, 2005^41^ | No | No | Yes | No | Unclear | No | Unclear - Uncertain representativeness of patients with IBD. | Fair – Potential selection bias.
Stocco, 2004^42^ | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear - Uncertain representativeness of patients with IBD. | Fair - HWE not reported. Compliance not clear. Avoidance of selection bias not clear.
Tamori, 2007^75^ | No | Unclear | Yes | Unclear | Unclear | No | Unclear – Unclear representativeness of Japanese patients with autoimmune hepatitis. Small sample size. | Fair - HWE not reported. Unclear if blinded outcome or genotype assessment.
Tani, 2009^76^ | No | No | Yes | Yes | No | No | Unclear – Unclear representativeness of patients with rheumatic diseases. Included only those in a tertiary care setting. | Fair - HWE not reported. Unclear if blinded outcome or genotype assessment. Unclear similarity of groups. Unclear if genotype was determined prospectively or retrospectively.
van Dieren, 2005^77^ | No | Unclear | Unclear | No | Unclear | Unclear | Unclear - Uncertain representativeness of patients with IBD. | Fair - Poor reporting of risk of bias items (only abstract available). Unclear if blinded outcome or genotype assessment. Inadequate description of genotyping method. Unclear reliability of genotyping method. Avoidance of selection bias is not clear.
von Ahsen, 2005^43^ | No | Unclear | Unclear | Yes | Unclear | Yes | Unclear - Uncertain representativeness of patients with IBD. Excluded those likely to experience adverse event. | Fair – Avoidance of selection bias is unclear. Unclear if blinded outcome or genotype assessment. Potential outcome reporting bias.
Winter, 2007^44^ | No | No | Yes | Yes | No | No | Unclear - Uncertain representativeness of patients with IBD. Included only those who had previously received thiopurines. | Fair - Unclear similarity of groups. Methods to control confounding not described.
Zelinkova, 2006^78^ | No | No | Yes | No | Unclear | Unclear | Unclear - Uncertain representativeness of patients with IBD. | Fair - Unclear if blinded outcome or genotype assessment. Avoidance of selection bias is unclear.
Newman, 2010^45^ | No | Yes | Yes | Yes | Unclear | No | Unclear -- excluded those likely to experience adverse event and no description provided of those who did not agree to participate | Good. The main study was an RCT.
Kolorz 2009^79^ | No | No | Yes | No | Unclear | No | Unclear -- little information is provided regarding sample selection and those who were included versus not | Fair – unclear blinded assessment of outcomes and comparability of groups

Abbreviations: DNA = deoxyribonucleic acid; HWE = Hardy-Weinberg equilibrium; IBD = inflammatory bowel disease; SLE = systemic lupus erythematosus; TPMT = thiopurine methyltransferase.

Table C-25 KQ 3c: Association between TPMT genotype and thiopurine toxicity – summary data

First Author, year | TPMT alleles tested | Outcomes and definition | Non-carriers | | Homozygotes | | Heterozygotes | | Homozygotes vs. non-carriers | Heterozygotes vs. non-carriers | Homozygotes vs. heterozygotes
First Author, year | TPMT alleles tested | Outcomes and definition | n with events | n without events | n with events | n without events | n with events | n without events | Odds Ratio (95% CI)
Ansari, 2008^28^ | TPMT *3A, *3B, *3C | WDAE NA | 66 | 122 | NR | NR | 15 | 4 | | 6.93 (2.21, 21.74)
Ansari, 2008^28^ | TPMT *3A, *3B, *3C | Hepatitis NR | 8 | 180 | NR | NR | 0 | 19 | | 0.54 (0.03, 9.8)
Ansari, 2008^28^ | TPMT *3A, *3B, *3C | Pancreatitis NR | 8 | 180 | NR | NR | 0 | 19 | | 0.54 (0.03, 9.8)
Ansari, 2008^28^ | TPMT *3A, *3B, *3C | Leukopenia WBC < 3500/mm3 or neutrophils < 1500/mm3 | 2 | 186 | NR | NR | 5 | 14 | | 33.21 (5.9, 186.88)
Hindorf, 2006^32^ | TPMT *2, *3A, *3B, *3C, *3D, *4, *5, *6, *7, *8, 10, *14, *15 | Hepatitis All types of hepatotoxic reactions | 15 | 25 | 4 | 2 | 0 | 6 | 3.33 (0.54, 20.45) | 0.13 (0.01, 2.41) | 23.4 (0.89, 613.02)
Hindorf, 2006^32^ | TPMT *2, *3A, *3B, *3C, *3D, *4, *5, *6, *7, *8, 10, *14, *15 | Pancreatitis NR | 13 | 27 | 2 | 4 | 0 | 6 | 1.04 (0.17, 6.42) | 0.16 (0.01, 2.99) | 7.22 (0.28, 189.2)
Hindorf, 2006^32^ | TPMT *2, *3A, *3B, *3C, *3D, *4, *5, *6, *7, *8, 10, *14, *15 | Myelotoxicity Included all types of haematological toxicity (anaemia, leucopoenia, neutropenia, thrombocytopenia) | 22 | 18 | 3 | 3 | 3 | 3 | 0.82 (0.15, 4.56) | 0.82 (0.15, 4.56) | 1 (0.1, 9.61)
Winter, 2007^44^ | TPMT *2, *3A, *3B, * 3C | Hepatitis deranged liver function tests | 8 | 111 | 0 | 0 | 1 | 10 | | 1.39 (0.16, 12.24)
Winter, 2007^44^ | TPMT *2, *3A, *3B, * 3C | Pancreatitis NR | 1 | 118 | 0 | 0 | 0 | 11 | | 3.43 (0.13, 89.24)
Winter, 2007^44^ | TPMT *2, *3A, *3B, * 3C | Leukopenia WBC < 3000/mm3 | 9 | 110 | 0 | 0 | 1 | 10 | | 1.22 (0.14, 10.65)
De Ridder, 2006^59^ | TPMT*2, *3A, *3B, *3C | Hepatitis Hepatotoxicity by serum alanine transaminase levels greater than twice the upper normal limit (50 IU/L) and resolution after withdrawal of AZA | 0 | 67 | 0 | 3 | 0 | 2
De Ridder, 2006^59^ | TPMT*2, *3A, *3B, *3C | Pancreatitis Severe abdominal pain and hyperamylasemi a and resolution after withdrawal of AZA | 4 | 63 | 0 | 3 | 0 | 2 | 2.02 (0.09, 45.36) | 2.82 (0.12, 68.1)
De Ridder, 2006^59^ | TPMT*2, *3A, *3B, *3C | Leukopenia Leucocyte count < 2.5x109 cells | 1 | 66 | 0 | 3 | 1 | 1 | 6.33 (0.22, 185.33) | 66 (2.2, 1984.33) | 0.14 (0, 5.95)
Black, 1998^57^ | TPMT *3A, TPMT*2 | Leukopenia Low leukocyte count | 0 | 61 | 0 | 0 | 5 | 1 | | 451 (16.35, 12442.54)
Black, 1998^57^ | TPMT *3A, TPMT*2 | Hepatitis Abnormal liver function test | 6 | 55 | 0 | 0 | 1 | 5 | | 1.83 (0.18, 18.41)
Ishioka, 1999^64^ | TPMT*1, *2, *3A, *3B, * 3C | Leukopenia WBC<4000/mm^3^ & 75% before administration | 4 | 29 | 0 | 0 | 3 | 0 | | 45.89 (2.02, 1044.27)
Derijks, 2004^60^ | TPMT *2, *3A, *3B, * 3C | Hepatitis Hepatotoxicity - ALT>80 U/L, AST>80 U/L, bilirubins > 40 μmol/L | 1 | 19 | 0 | 1 | 0 | 4 | 4.33 (0.12, 159.53) | 1.44 (0.05, 41.62)
Derijks, 2004^60^ | TPMT *2, *3A, *3B, * 3C | Pancreatitis Pancreatitis - amylase > 220 U/L, lipase > 120 U/L (elevations>2times normal upper limit) | 3 | 17 | 0 | 1 | 0 | 4 | 1.67 (0.06, 49.95) | 0.56 (0.02, 12.82)
Derijks, 2004^60^ | TPMT *2, *3A, *3B, * 3C | Leukopenia Myelotoxicity (leukocyte count < 4.0 × 109/L, platelet count < 100 × 109/L) | 1 | 19 | 1 | 0 | 2 | 2 | 39 (1.06, 1435.74) | 19 (1.15, 314.99) | 3 (0.08, 115.35)
Gearry, 2004^62^ | TPMT*1, *2, *3A, 3C | Hepatitis Hepatitis: elevation of serum liver transaminases greater than twice the upper limit of normal | 18 | 115 | 0 | 1 | 0 | 13 | 2.08 (0.08, 53.04) | 0.23 (0.01, 4.06)
Gearry, 2004^62^ | TPMT*1, *2, *3A, 3C | Pancreatitis Pancreatitis: severe abdominal pain associated with an elevation of serum amylase greater than three times the upper limit of normal | 5 | 128 | 0 | 1 | 2 | 11 | 7.79 (0.28, 213.81) | 4.65 (0.81, 26.83) | 1.53 (0.05, 49.8)
Gearry, 2004^62^ | TPMT*1, *2, *3A, 3C | Leukopenia WBC < 3000/mm3 or neutrophils < 2000/mm3 | 2 | 131 | 1 | 0 | 1 | 12 | 157.8 (5.08, 4904.53) | 5.46 (0.46, 64.67) | 25 (0.67, 934.5)
Joji, 2003^66^ | TPMT *1, *2, *3A, *3B, * 3C | Leukopenia WBC<3000/mm^3^ | 12 | 13 | 0 | 0 | 2 | 0 | | 5.4 (0.24, 123.81)
Joji, 2003^66^ | TPMT *1, *2, *3A, *3B, * 3C | Myelotoxicity Pancytopenia | 1 | 24 | 0 | 0 | 0 | 2 | | 3.27 (0.1, 103.43)
Hibi, 2003^63^ | TPMT *2, 3B, *3A, *3C | Leukopenia WBC < 3000/mm3 | 5 | 69 | 1 | 0 | 6 | 1 | 37.91 (1.38, 1044.73) | 82.8 (8.27, 828.71) | 0.69 (0.02, 26.91)
Corominas, 2003^58^ | TPMT *2, *3A, *3B, *3C, *7, *8 | WDAE NA | 3 | 32 | 0 | 0 | 3 | 2 | | 16 (1.87, 136.7)
Dubinsky, 2000^61^ | TPMT *3A, *3B, *3C | Leukopenia WBC<4000/mm3 | 12 | 72 | 0 | 0 | 1 | 7 | | 0.86 (0.1, 7.6)
Bezier, 2008^56^ | TPMT*2, *3A, *3B, *3C | Any infection (including sepsis) Grade 1 (minor) to grade 4 (sepsis with hypotension) | 9 | 22 | 0 | 0 | 0 | 2 | | 0.47 (0.02, 10.83)
Bezier, 2008^56^ | TPMT*2, *3A, *3B, *3C | WDAE NA | 15 | 16 | 0 | 0 | 1 | 1 | | 1.07 (0.06, 18.62)
Bezier, 2008^56^ | TPMT*2, *3A, *3B, *3C | Leukopenia WBC <3.9 x 10^9^/L | 8 | 23 | 0 | 0 | 0 | 2 | | 0.55 (0.02, 12.73)
Bezier, 2008^56^ | TPMT*2, *3A, *3B, *3C | Neutropenia WMC <1.9 x 10^9^/L | 4 | 27 | 0 | 0 | 0 | 2 | | 1.22 (0.05, 29.86)
Bezier, 2008^56^ | TPMT*2, *3A, *3B, *3C | Anemia <109 g/L | 7 | 24 | 0 | 0 | 0 | 2 | | 0.65 (0.03, 15.16)
Reuther, 2003^71^ | TPMT *3A, *3B, *3C | Hepatitis Alanine transaminase levels twice the upper normal level (40 U/L) | 0 | 62 | 0 | 0 | 0 | 4
Reuther, 2003^71^ | TPMT *3A, *3B, *3C | Leukopenia WBC less than 3x10^9^/L | 0 | 62 | 0 | 0 | 0 | 4
Stocco, 2005^41^ | TPMT *2, *3A, *3B, *3C | Hepatitis ALT, GGT or alkaline phosphatase more than twice normal levels | 6 | 59 | 0 | 0 | 0 | 5 | | 0.83 (0.04, 16.82)
Stocco, 2005^41^ | TPMT *2, *3A, *3B, *3C | Pancreatitis Severe abdominal pain, accompanied by serum amylase level of greater than twice normal levels | 4 | 61 | 0 | 0 | 0 | 5 | | 1.24 (0.06, 26.21)
Stocco, 2005^41^ | TPMT *2, *3A, *3B, *3C | Myelotoxicity Leucopoenia (WBC < 3000mm^3^) and/or thrombocytopenia (platelets < 100,000mm^3^) | 7 | 58 | 0 | 0 | 0 | 5 | | 0.71 (0.04, 14.15)
Zelinkova, 2006^78^ | TPMT *1, *2, *3A, *3B, *3C | Leukopenia WBC < 3x10^9/L resolving after discontinuation or dose reduction | 8 | 230 | 1 | 0 | 3 | 20 | 81.35 (3.08, 2147.05) | 4.31 (1.06, 17.55) | 17.57 (0.59, 524.14)
Zelinkova, 2006^78^ | TPMT *1, *2, *3A, *3B, *3C | Hepatitis Hepatotoxicity - serum alanine transaminase levels greater than twice the upper normal limit (45 U/L) and resolution after withdrawal or dose reduction | 9 | 229 | 0 | 0 | 2 | 22 | | 2.31 (0.47, 11.38)
Okada, 2005^37^ | TPMT *2, *3A, *3B, *3C | Leukopenia WBC < 2300/mm3 | 2 | 14 | 0 | 0 | 1 | 1 | | 7 (0.3, 162.21)
Stocco, 2007^74^ | TPMT *2, *3A, *3B, *3C | Pancreatitis Severe abdominal pain accompanied by serum amylase level more than twice the normal limit | 6 | 59 | 0 | 0 | 1 | 4 | | 2.46 (0.24, 25.69)
Stocco, 2007^74^ | TPMT *2, *3A, *3B, *3C | Hepatitis NR | 3 | 64 | 0 | 0 | 0 | 3 | | 2.63 (0.11, 61.59)
Stocco, 2007^74^ | TPMT *2, *3A, *3B, *3C | Leukopenia NR | 2 | 65 | 0 | 0 | 0 | 3 | | 3.74 (0.15, 93.79)
Stocco, 2007^74^ | TPMT *2, *3A, *3B, *3C | Thrombocytopenia NR | 1 | 66 | 0 | 0 | 0 | 3 | | 6.33 (0.22, 185.33)
Tamori, 2007^75^ | TPMT *2, *3A, *3B, *3C | Myelotoxicity Thrombocytopenia, granulocytopenia and neutropenia | 1 | 7 | 1 | 0 | 0 | 0 | 15 (0.39, 576.73)
Marinaki, 2004^69^ | TPMT *2, *3A, *3C | Hepatitis Serum alanine transaminase levels greater than twice upper normal limit (50 IU/L) and resolution after withdrawal of AZA | 3 | 110 | 0 | 0 | 1 | 16 | | 2.29 (0.22, 23.39)
Marinaki, 2004^69^ | TPMT *2, *3A, *3C | Pancreatitis Severe abdominal pain and serum amylase > 800 U/L | 7 | 106 | 0 | 0 | 1 | 16 | | 0.95 (0.11, 8.21)
Marinaki, 2004^69^ | TPMT *2, *3A, *3C | Neutropenia Neutrophil count of <2x10^9^ cells | 10 | 103 | 0 | 0 | 1 | 16 | | 0.64 (0.08, 5.37)
von Ahsen, 2005^43^ | TPMT *2, *3A, *3B, *3C | Hepatitis Aspartate or alanine aminotransferase 2 times the upper limit of reference interval | 3 | 63 | 0 | 0 | 0 | 5 | | 1.65 (0.08, 36.2)
von Ahsen, 2005^43^ | TPMT *2, *3A, *3B, *3C | Pancreatitis Upper abdominal pain with pancreatic amylase or lipase 2 times the upper limit of the reference interval | 1 | 65 | 0 | 0 | 1 | 4 | | 16.25 (0.85, 310.48)
von Ahsen, 2005^43^ | TPMT *2, *3A, *3B, *3C | Myelotoxicity Myelosuppression - leukocyte counts < 2.5x10^9^/L or platelet counts <100x10^9^/L | 0 | 66 | 0 | 0 | 0 | 5
Jun, 2005^67^ | TPMT *2, *3A, *3B, *3C, 3D, *6 | Hepatitis >= Two fold elevation of upper normal limit | 1 | 86 | 0 | 0 | 0 | 7 | | 3.84 (0.14, 102.83)
Jun, 2005^67^ | TPMT *2, *3A, *3B, *3C, 3D, *6 | Leukopenia WBC < 4000 mm^3^ and <75% before administration | 16 | 71 | 0 | 0 | 1 | 6 | | 0.74 (0.08, 6.58)
Stocco, 2004^42^ | TPMT *2, *3A, *3B, * 3C | Any infection (including sepsis) Infection documented clinically or microbiologically | 3 | 37 | 0 | 0 | 0 | 4 | | 1.19 (0.05, 26.97)
Stocco, 2004^42^ | TPMT *2, *3A, *3B, * 3C | Hepatitis ALT, GGT or alkaline phosphatase more than twice their normal levels | 2 | 38 | 0 | 0 | 0 | 4 | | 1.71 (0.07, 41.54)
Stocco, 2004^42^ | TPMT *2, *3A, *3B, * 3C | Pancreatitis Severe abdominal pain, accompanied by a serum amylase level of greater than twice their normal levels | 2 | 38 | 0 | 0 | 0 | 4 | | 1.71 (0.07, 41.54)
Stocco, 2004^42^ | TPMT *2, *3A, *3B, * 3C | Myelotoxicity WBC count < 3000 cells/mm3, and platelets < 100,000/mm^3^ | 13 | 27 | 0 | 0 | 0 | 4 | | 0.23 (0.01, 4.52)
Snow, 1995^39^ | NR | Hepatitis 9 (Raised AST and ALT) | 1 | 20 | 0 | 0 | 0 | 5 | | 1.24 (0.04, 34.93)
Snow, 1995^39^ | NR | Leukopenia NR | 1 | 20 | 0 | 0 | 2 | 3 | | 13.33 (0.91, 196.38)
Tani, 2009^76^ | TPMT*2, *3A, *3B, *3C | WDAE NA | 18 | 58 | 0 | 1 | 0 | 1 | 1.05 (0.04, 27) | 1.05 (0.04, 27)
Tani, 2009^76^ | TPMT*2, *3A, *3B, *3C | Leukopenia <3000/mm^3^ | 7 | 69 | 0 | 1 | 0 | 1 | 3.09 (0.12, 82.76) | 3.09 (0.12, 82.76)
Tani, 2009^76^ | TPMT*2, *3A, *3B, *3C | Thrombocytopenia <100000/mm^3^ | 1 | 75 | 0 | 1 | 0 | 1 | 16.78 (0.47, 605.23) | 16.78 (0.47, 605.23)
Tani, 2009^76^ | TPMT*2, *3A, *3B, *3C | Any infection (including sepsis) NR | 4 | 72 | 0 | 1 | 0 | 1 | 5.37 (0.19, 151.44) | 5.37 (0.19, 151.44)
Palmieri, 2007^70^ | TPMT *3A, *3B, *3C | Pancreatitis Upper abdominal pain with pancreatic amylase and lipase greater than twice the normal upper limit | 16 | 377 | 0 | 2 | 0 | 27 | 4.58 (0.21, 99.18) | 0.42 (0.02, 7.12)
Palmieri, 2007^70^ | TPMT *3A, *3B, *3C | Leukopenia WBC <3.0 x 10^9^/L | 17 | 376 | 2 | 0 | 4 | 23 | 107.57 (4.97, 2326.61) | 3.85 (1.2, 12.37) | 26.11 (1.06, 640.27)
Palmieri, 2007^70^ | TPMT *3A, *3B, *3C | Hepatitis Serum alanine transaminase increase greater than twice the upper normal limit and resolution after withdrawal or dose reduction | 11 | 382 | 0 | 2 | 1 | 26 | 6.65 (0.3, 146.57) | 1.34 (0.17, 10.75) | 3.53 (0.11, 111.68)
Jae Hak, 2008^65^ | TPMT *1, *2, *3A, *3B, *3C | Leukopenia WBC<3.0 x 10^9^/L | 113 | 166 | 0 | 0 | 5 | 2 | | 3.67 (0.7, 19.26)
Schmeling, 2007^72^ | TPMT *2, *3A, *3B, *3C | Leukopenia WBC <3.0x 10^9/L | 4 | 48 | 0 | 0 | 2 | 2 | | 12 (1.32, 109.34)
Schmeling, 2007^72^ | TPMT *2, *3A, *3B, *3C | Hepatitis LFT >100U/L | 12 | 40 | 0 | 0 | 0 | 4 | | 0.36 (0.02, 7.16)
Lopez, 2006^68^ | TPMT*2, *3A, *3B, *3C, *3D | Pancreatitis NR | 52 | 50 | 0 | 0 | 1 | 4 | | 0.24 (0.03, 2.23)
Seddik, 2003^73^ | TPMT *2, *3A, *3B, *3C | Leukopenia WBC <3.0 x 10^9^/L | 6 | 63 | 0 | 0 | 1 | 5 | | 2.1 (0.21, 21.04)
van Dieren, 2005^77^ | NR | Hepatitis NR | 8 | 77 | 0 | 1 | 0 | 10 | 3.04 (0.11, 80.61) | 0.43 (0.02, 8.08)
van Dieren, 2005^77^ | NR | Leukopenia NR | 6 | 79 | 1 | 0 | 2 | 8 | 36.69 (1.35, 993.86) | 3.29 (0.57, 19.09) | 10.2 (0.31, 336.95)
van Dieren, 2005^77^ | NR | Thrombocytopenia NR | 0 | 85 | 1 | 0 | 0 | 10 | 513 (7.4, 35584.39) | | 63 (0.87, 4537.84)
Stassen, 2009^40^ | TPMT *2, *3A, *3B, *3C | Leukopenia NR | 34 | 67 | 0 | 0 | 3 | 4 | | 1.48 (0.31, 6.98)
Stassen, 2009^40^ | TPMT *2, *3A, *3B, *3C | Thrombocytopenia NR | 8 | 93 | 0 | 0 | 0 | 7 | | 0.73 (0.04, 13.98)
Stassen, 2009^40^ | TPMT *2, *3A, *3B, *3C | Anemia NR | 30 | 70 | 0 | 0 | 3 | 4 | | 1.75 (0.37, 8.30)
Newman, 2010^45^ | TPMT *2, *3A, *3B, *3C | Mortality | 3 | 147 | 0 | 1 | 0 | 15 | 14.05 (0.48, 409.13) | 1.36 (0.07, 27.55)
| | WDAE | 0 | 150 | 0 | 1 | 0 | 15
| | SAE | 7 | 143 | 1 | 0 | 0 | 15 | 57.4 (2.15, 1531.14) | 0.62 (0.03, 11.33) | 93 (1.31, 6606.26)
| | Hepatitis | 8 | 142 | 0 | 1 | 0 | 15 | 5.59 (0.21, 147.71) | 0.54 (0.03, 9.83)
| | Pancreatitis | 4 | 146 | 0 | 1 | 0 | 15 | 10.85 (0.39, 304.77) | 1.05 (0.05, 20.43)
| | Neutropenia | 0 | 150 | 1 | 0 | 0 | 15 | 903 (13.05, 62488.75) | | 93 (1.31, 6606.26)
Kolorz 2009^79^ | TPMT *2, *3A, *3B, *3C | Leukopenia | 16 | 64 | 0 | 0 | 5 | 2 | | 10 (1.77, 56.35)

Abbreviations: ALT = Alanine transaminase; AZA = azathioprine; GGT = Gamma-glutamyl transferase; L = liter; LFT = liver function test; mm = millimetre; NR = not reported; TPMT = thiopurine methyltransferase; WBC = white blood cell count; U = Unit of enzymatic activity = nanomole of product per hour; WDAE = withdrawal due to adverse events; SAE = serious adverse event

## Key Question 4 For patients with chronic autoimmune disease, costs of TPMT testing, and treating drug-associated complications

Table C-26 KQ 4: Costs of TPMT testing

Study | Currency | Year of costing data | Source of costing data | Type of test | Costing details | Cost reported in study | Converted to USD 2009^*^
Hagaman 2010^80^ | NZ | 2007 | Not reported | Phenotype | Not reported | $300.00 | $320.98
Gurwitz 2009^81^ | GBP | 2006 | Estimated from a RCT | Genotype | Cost of test per patient | $30.00 | $61.67
Gurwitz 2009^81^ | Euro | 2006 | UCB Pharma (Spain) | Phenotype | Cost of test per patient | $40.00 | $58.57
Gurwitz 2009^81^ | GBP | 2006 | Average from the Guy's Hospital and the London City Hospital | Phenotype | Cost of test per patient | $29.00 | $59.61
Compagni 2008^82^ | Euro | 2006 | Survey of European labs | Genotype TPMT*1, *2, *3A, *3B, *3C | Pharmacogenetickits, cost per patient | $33.00 | $46.25
Compagni 2008^82^ | Euro | 2006 | Survey of European labs | Genotype TPMT*2, *3A, *3B, *3C | Pharmacogenetickits, cost per patient | $21.00 | $29.43
Compagni 2008^82^ | Euro | 2006 | Survey of European labs | Genotype | DNA extraction, PCR, technician time total costs per patient | $20.00 to $100.00 | $28.03 to $140.14
Sayani 2005^83^ | CAD | 2005 | Alberta’s provincial laboratory fees | Phenotype | Cost of test per patient | $50.00 | $47.95
Priest 2006^84^ | USD | 2004 | Cost at local lab | Genotype | Cost of test per patient | $78.00 | $94.48
Priest 2006^84^ | USD | 2004 | Cost at local lab | Phenotype | Cost of test per patient | $57.75 | $46.36
Dubinsky 2005^85^ | USD | 2004 | Author's estimate based on literature search (private lab costs) | Genotype | Cost of test per patient | $510.06 | $617.80
Winter 2004^86^ | GBP | 2003 | Cost at local lab | Genotype | Cost of test per patient | $30.00 | $61.92
Oh 2004^87^ | USD | 2002 | Hanyang University Hospital, Seoul | Genotype | Cost of test per patient | $100.00 | $131.51
Marra 2002^88^ | CAD | 1999 | Based on other PCR tests | Genotype | Cost of test per patient | $100.00 | $100.88
Tavadia 2000^89^ | CAD | 1999 | Cost at local lab and other PCR tests | Genotype | Cost of test per patient | $100.00 | $100.88

Note:

* inflation and conversion rate.

Abbreviations: CAD = Canadian dollar; DNA = deoxyribonucleic acid; Euro = European Union dollar; GBP = British pound; PCR = polymerase chain reaction; RCT=randomized controlled trial; TPMT = thiopurine methyltransferase; USD = United States dollar.

Table C-27 KQ 4: Costs of treating azathioprine-associated complications

Study | Currency, year of data | Source of costing data | Costing item | Costing details | Cost reported in study | Converted to USD 2009^*^
Prakshar 1995^90^ | USD, 1995 | Accounting data of 3 US hospitals | One-time cost of adverse drug events (low range) | Derived by assuming that 10% of patients developed side-effect that is resolved in 6 months | $802.41 | $1366.82
Prakshar 1995^90^ | USD, 1995 | Accounting data of 3 US hospitals | One-time cost of adverse drug events (high range) | Derived by assuming that 30% patients developed side-effect that is resolved in 6 months | $2407.22 | $4100.45
Tavadia 2000^89^ | CAD, 1999 | Sunnybrook and Women's College Health Centre | One-time cost of adverse drug events | | $7048.00 | $7110.02
Marra 2002^88^ | CAD, 1999 | Canadian provincial guide to medical fees | One-time cost of adverse drug events | Derived by assuming 50% will require outpatient and 50% will require inpatient care | $1734.50 | $1749.76
Winter 2004^86^ | GBP, 2003 | Information and statistics division of Common Services Agency | One-time cost of adverse drug events | Derived by assuming 32% will develop leukopenia | $1367.00 | $2821.66
Oh 2004^87^ | USD, 2002 | Hanyang University Hospital, Seoul | One-time cost of adverse drug events | Average of 4 cases with AZA-induced neutropenia | $2501.00 | $3289.13
Priest 2006^84^ | USD, 2004 | Local public hospital in New Zealand | One-time cost of adverse drug events | Average costs of life-threatening, severe, and moderate leukopenia | $5009.67 | $6067.82
Hagaman 2010^80^ | USD, 2007 | DRG 420, Professional costs | One-time cost of adverse drug events | Average cost of complicated leukopenia and uncomplicated leukopenia | $5279.50 | $5648.65
Hagaman 2010^80^ | USD, 2007 | DRG 420, Professional costs | One-time cost of adverse drug events | Cost of complicated leukopenia leading to death | $14666.00 | $15691.46

Note:

* inflation and conversion rate.

Abbreviation: AZA = azathiopurine; CAD = Canadian dollar; GBP = British pound; USD = United States dollar.

## References

1 Jacqz-Aigrain E, Bessa E, Medard Y, et al. Thiopurine methyltransferase activity in a French population: h.p.l.c. assay conditions and effects of drugs and inhibitors. British Journal of Clinical Pharmacology. 07. 1994;38(1):1-8. [pmid: 7946931].
2 Lennard L, Singleton HJ. High-performance liquid chromatographic assay of human red blood cell thiopurine methyltransferase activity. Journal of Chromatography B: Biomedical Applications. 11. 4. 1994;661(1):25-33.
3 Lennard L, Chew TS, Lilleyman JS. Human thiopurine methyltransferase activity varies with red blood cell age. British Journal of Clinical Pharmacology. 11. 2001;52(5):539-46. [pmid: 11736862].
4 Weinshilboum RM, Raymond FA, Pazmino PA. Human erythrocyte thiopurine methyltransferase: radiochemical microassay and biochemical properties. Clinica Chimica Acta. 05. 2. 1978;85(3):323-33.
5 Indjova D, Shipkova M, Atanasova S, et al. Determination of thiopurine methyltransferase phenotype in isolated human erythrocytes using a new simple nonradioactive HPLC method. Ther Drug Monit. 10. 2003;25(5):637-44. [pmid: 14508388].
6 Shipkova M, Niedmann PD, Armstrong VW, et al. Determination of thiopurine methyltransferase activity in isolated human erythrocytes does not reflect putative in vivo enzyme inhibition by sulfasalazine. Clin Chem. 02. 2004;50(2):438-41. [pmid: 14752016].
7 Zhang LR, Song DK, Zhang W, et al. Efficient screening method of the thiopurine methyltransferase polymorphisms for patients considering taking thiopurine drugs in a Chinese Han population in Henan Province (central China). Clinica Chimica Acta. 02. 2007;376(1–2):45-51.
8 Indjova D, Atanasova S, Shipkova M, et al. Phenotypic and genotypic analysis of thiopurine s-methyltransferase polymorphism in the bulgarian population. Ther Drug Monit. 10. 2003;25(5):631-6. [pmid: 14508387].
9 Anglicheau D, Sanquer S, Loriot MA, et al. Thiopurine methyltransferase activity: new conditions for reversed-phase high-performance liquid chromatographic assay without extraction and genotypic-phenotypic correlation. Journal of Chromatography B: Analytical Technologies in the Biomedical & Life Sciences. 06. 25. 2002;773(2):119-27.
10 Dervieux T, Medard Y, Verpillat P, et al. Possible implication of thiopurine S-methyltransferase in occurrence of infectious episodes during maintenance therapy for childhood lymphoblastic leukemia with mercaptopurine. Leukemia. 11. 2001;15(11):1706-12. [pmid: 11681411].
11 Dervieux T, Medard Y, Baudouin V, et al. Thiopurine methyltransferase activity and its relationship to the occurrence of rejection episodes in paediatric renal transplant recipients treated with azathioprine. British Journal of Clinical Pharmacology. 12. 1999;48(6):793-800. [pmid: 10594482].
12 Medard Y, Nafa S, Jacqz-Aigrain E. Thiopurine methyltransferase activity: new high-performance liquid chromatographic assay conditions. Journal of Chromatography. 1997. 10. 24. B, Biomedical Sciences & Applications. 700(1–2):275-7.
13 Menor C, Fueyo JA, Escribano O, et al. Determination of thiopurine methyltransferase activity in human erythrocytes by high-performance liquid chromatography: comparison with the radiochemical method. Ther Drug Monit. 10. 2001;23(5):536-41. [pmid: 11591900].
14 Ganiere-Monteil C, Pineau A, Kergueris MF, et al. Thiopurine methyl transferase activity: new extraction conditions for high-performance liquid chromatographic assay. Journal of Chromatography B: Biomedical Sciences & Applications. 04. 30. 1999;727(1–2):235-9.
15 Escousse A, Guedon F, Mounie J, et al. 6-Mercaptopurine pharmacokinetics after use of azathioprine in renal transplant recipients with intermediate or high thiopurine methyl transferase activity phenotype. J Pharm Pharmacol. 11. 1998;50(11):1261-6. [pmid: 9877312].
16 Whalen CE, Tamary H, Greenberg M, et al. Analysis of 6-mercaptopurine in serum or plasma using high performance liquid chromatography. Ther Drug Monit. 1985;7(3):315-20. [pmid: 4049471].
17 Johnson-Davis K, Juenke J, Pickering J, et al. An enzymatic assay used to identify patients with low thiopurine methyltransferase (TPMT) activity. Clin Chem. 2008;54.
18 Khalil MN, Erb N, Khalil PN, et al. Interference free and simplyfied liquid chromatography-based determination of thiopurine S-methyltransferase activity in erythrocytes.[erratum appears in J Chromatogr B Analyt Technol Biomed Life Sci. 2005 Sep 25;824(1–2):348–50]. Journal of Chromatography B: Analytical Technologies in the Biomedical & Life Sciences. 07. 5. 2005;821(1):105-11.
19 Ganiere-Monteil C, Medard Y, Lejus C, et al. Phenotype and genotype for thiopurine methyltransferase activity in the French Caucasian population: impact of age. Eur J Clin Pharmacol. 04. 2004;60(2):89-96. [pmid: 15022030].
20 Zhang B, Xu X, Zeng X, et al. Correlation of thiopurine methyltransferase activity and 6-thioguanine nucleotide concentration in Han Chinese patients treated with azathioprine 25 to 100 mg: A 1-year, single-center, prospective study. Curr Therap Res - Clin Experiment. 2006;67(4):270-82.
21 Keizer-Garritsen JJ, Brouwer C, Lambooy LH, et al. Measurement of thiopurine S-methyltransferase activity in human blood samples based on high-performance liquid chromatography: reference values in erythrocytes from children. Ann Clin Biochem. 01. 2003;40(Pt 1):86-93. [pmid: 12542916].
22 Oselin K, Anier K, Tamm R, et al. Determination of thiopurine S-methyltransferase (TPMT) activity by comparing various normalization factors: reference values for Estonian population using HPLC-UV assay. Journal of Chromatography B: Analytical Technologies in the Biomedical & Life Sciences. 04. 13. 2006;834(1–2):77-83.
23 Kroplin T, Weyer N, Gutsche S, et al. Thiopurine S-methyltransferase activity in human erythrocytes: a new HPLC method using 6-thioguanine as substrate. Eur J Clin Pharmacol. 05. 1998;54(3):265-71. [pmid: 9681671].
24 Lentz JJ, Cunnigham J, Winland M, et al. Performance evaluation of a thiopurine methyltransferase (TPMT) enzyme activity assay by reversed-phase HPLC. Am J Gastroenterol. 2000;95(9).
25 Ford L, Graham V, Berg J. Whole-blood thiopurine S-methyltransferase activity with genotype concordance: a new, simplified phenotyping assay. Ann Clin Biochem. 09. 2006;43(Pt 5):354-60. [pmid: 17036413].
26 Ford LT, Cooper SC, Lewis MJ, et al. Reference intervals for thiopurine S-methyltransferase activity in red blood cells using 6-thioguanine as substrate and rapid non-extraction liquid chromatography.[see comment]. Ann Clin Biochem. 07. 2004;41(Pt 4):303-8. [pmid: 15298742].
27 Decaux G, Horsmans Y, Houssiau F, et al. High 6-thioguanine nucleotide levels and low thiopurine methyltransferase activity in patients with lupus erythematosus treated with azathioprine. Am J Therapeut. 05. 2001;8(3):147-50.
28 Ansari A, Arenas M, Greenfield SM, et al. Prospective evaluation of the pharmacogenetics of azathioprine in the treatment of inflammatory bowel disease. Aliment Pharmacol Ther. 10. 15. 2008;28(8):973-83. [pmid: 18616518].
29 Ansari A, Hassan C, Duley J, et al. Thiopurine methyltransferase activity and the use of azathioprine in inflammatory bowel disease. Aliment Pharmacol Ther. 10. 2002;16(10):1743-50. [pmid: 12269967].
30 Gardiner SJ, Gearry RB, Begg EJ, et al. Thiopurine dose in intermediate and normal metabolizers of thiopurine methyltransferase may differ three-fold. Clin Gastroenterol Hepatol. 06. 2008;6(6):654-60. [pmid: 18467186].
31 Haglund S, Lindqvist M, Almer S, et al. Pyrosequencing of TPMT alleles in a general Swedish population and in patients with inflammatory bowel disease.[erratum appears in Clin Chem. 2004 Apr;50(4):788]. Clin Chem. 02. 2004;50(2):288-95. [pmid: 14656901].
32 Hindorf U, Lindqvist M, Hildebrand H, et al. Adverse events leading to modification of therapy in a large cohort of patients with inflammatory bowel disease. Aliment Pharmacol Ther. 07. 15. 2006;24(2):331-42. [pmid: 16842460].
33 Hindorf U, Lyrenas E, Nilsson A, et al. Monitoring of long-term thiopurine therapy among adults with inflammatory bowel disease. Scand J Gastroenterol Suppl. 11. 2004;39(11):1105-12.
34 Langley PG, Underhill J, Tredger JM, et al. Thiopurine methyltransferase phenotype and genotype in relation to azathioprine therapy in autoimmune hepatitis. J Hepatol. 10. 2002;37(4):441-7. [pmid: 12217596].
35 Lindqvist M, Hindorf U, Almer S, et al. No induction of thiopurine methyltransferase during thiopurine treatment in inflammatory bowel disease. Nucleosides Nucleotides Nucleic Acids. 2006;25(9–11):1033-7. [pmid: 17065060].
36 Marinaki AM, Arenas M, Khan ZH, et al. Genetic determinants of the thiopurine methyltransferase intermediate activity phenotype in British Asians and Caucasians. Pharmacogenetics. 02. 2003;13(2):97-105. [pmid: 12563179].
37 Okada Y, Nakamura K, Kodama T, et al. Thiopurine methyltransferase genotype and phenotype status in Japanese patients with systemic lupus erythematosus. Biol Pharm Bull. 11. 2005;28(11):2117-9. [pmid: 16272700].
38 Schwab M, Schaffeler E, Marx C, et al. Azathioprine therapy and adverse drug reactions in patients with inflammatory bowel disease: impact of thiopurine S-methyltransferase polymorphism.[see comment]. Pharmacogenetics. 08. 2002;12(6):429-36. [pmid: 12172211].
39 Snow JL, Gibson LE. The role of genetic variation in thiopurine methyltransferase activity and the efficacy and/or side effects of azathioprine therapy in dermatologic patients.[see comment]. Arch Dermatol. 02. 1995;131(2):193-7. [pmid: 7857117].
40 Stassen PM, Derks RP, Kallenberg CG, et al. Thiopurinemethyltransferase (TPMT) genotype and TPMT activity in patients with anti-neutrophil cytoplasmic antibody-associated vasculitis: relation to azathioprine maintenance treatment and adverse effects. Ann Rheum Dis. 05. 2009;68(5):758-9. [pmid: 19366895].
41 Stocco G, Martelossi S, Barabino A, et al. TPMT genotype and the use of thiopurines in paediatric inflammatory bowel disease. Dig Liver Dis. 12. 2005;37(12):940-5. [pmid: 16202677].
42 Stocco G, Martelossi S, Decorti G, et al. Pharmacogenetics of thiopurines: Can posology be guided by laboratory data. Radiol Oncol. 2004;38(2):101-9. +157.
43 von Ahsen N, Armstrong VW, Behrens C, et al. Association of inosine triphosphatase 94C>A and thiopurine S-methyltransferase deficiency with adverse events and study drop-outs under azathioprine therapy in a prospective Crohn disease study.[erratum appears in Clin Chem. 2006 Aug;52(8):1628 Note: Schutz, Ekkehard [added]]. Clin Chem. 12. 2005;51(12):2282-8. [pmid: 16214825].
44 Winter JW, Gaffney D, Shapiro D, et al. Assessment of thiopurine methyltransferase enzyme activity is superior to genotype in predicting myelosuppression following azathioprine therapy in patients with inflammatory bowel disease.[see comment]. Aliment Pharmacol Ther. 05. 1. 2007;25(9):1069-77. [pmid: 17439508].
45 Newman W, Payne K, Tricker K, Roberts S, Fargher E, Pushpakom S, Alder J, Sidgwick G, Payne D, Elliott R, et al. A pragmatic randomised controlled trial of thiopurine methyltransferase (TPMT) genotyping in the managment of patients, prior to azathioprine treatment: The TARGET study[Draft]. 2010. Unpublished work.
46 Hindorf U, Jahed K, Bergquist A, et al. Characterisation and utility of thiopurine methyltransferase and thiopurine metabolite measurements in autoimmune hepatitis. J Hepatol. 2010;52(1):106-11. [pmid: 19906459].
47 Banerjee S, Bishop WP. Evolution of thiopurine use in pediatric inflammatory bowel disease in an academic center.[see comment]. J Pediatr Gastroenterol Nutr. 09. 2006;43(3):324-30. [pmid: 16954954].
48 Czaja AJ, Carpenter HA. Thiopurine methyltransferase deficiency and azathioprine intolerance in autoimmune hepatitis. Dig Dis Sci. 05. 2006;51(5):968-75. [pmid: 16773433].
49 Firooz A, Ghandi N, Hallaji Z, et al. Role of thiopurine methyltransferase activity in the safety and efficacy of azathioprine in the treatment of pemphigus vulgaris. Arch Dermatol. 09. 2008;144(9):1143-7. [pmid: 18794458].
50 Gisbert JP, Nino P, Rodrigo L, et al. Thiopurine methyltransferase (TPMT) activity and adverse effects of azathioprine in inflammatory bowel disease: long-term follow-up study of 394 patients. Am J Gastroenterol. 12. 2006;101(12):2769-76. [pmid: 17026564].
51 Kader HA, Wenner WJ Jr, Telega GW, et al. Normal thiopurine methyltransferase levels do not eliminate 6-mercaptopurine or azathioprine toxicity in children with inflammatory bowel disease. J Clin Gastroenterol. 06. 2000;30(4):409-13. [pmid: 10875470].
52 Lennard L, Van Loon JA, Weinshilboum RM. Pharmacogenetics of acute azathioprine toxicity: relationship to thiopurine methyltransferase genetic polymorphism. Clin Pharmacol Ther. 08. 1989;46(2):149-54. [pmid: 2758725].
53 Schedel J, Godde A, Schutz E, et al. Impact of thiopurine methyltransferase activity and 6-thioguanine nucleotide concentrations in patients with chronic inflammatory diseases. Ann N Y Acad Sci. 06. 2006;1069:477-91. [pmid: 16855176].
54 Shah JA, Edwards CM, Probert CS. Should azathioprine and 5-aminosalicylates be coprescribed in inflammatory bowel disease?: an audit of adverse events and outcome. Eur J Gastroenterol Hepatol. 03. 2008;20(3):169-73. [pmid: 18301295].
55 Stolk JN, Boerbooms AM, De Abreu RA, et al. Reduced thiopurine methyltransferase activity and development of side effects of azathioprine treatment in patients with rheumatoid arthritis. Arthritis Rheum. 10. 1998;41(10):1858-66. [pmid: 9778228].
56 Bezier M, Reguiai Z, Vitry F, et al. Thiopurine S-methyltransferase genotypic analysis in autoimmune bullous diseases. European Journal of Dermatology. 09. 2008;18(5):512-7. [pmid: 18693152].
57 Black AJ, McLeod HL, Capell HA, et al. Thiopurine methyltransferase genotype predicts therapy-limiting severe toxicity from azathioprine. Ann Intern Med. 11. 1. 1998;129(9):716-8. [pmid: 9841604].
58 Corominas H, Domenech M, Laiz A, et al. Is thiopurine methyltransferase genetic polymorphism a major factor for withdrawal of azathioprine in rheumatoid arthritis patients?. Rheumatology. 01. 2003;42(1):40-5. [pmid: 12509611].
59 De RL, Van Dieren JM, Van Deventer HJ, et al. Pharmacogenetics of thiopurine therapy in paediatric IBD patients. Aliment Pharmacol Ther. 04. 15. 2006;23(8):1137-41. [pmid: 16611274].
60 Derijks LJ, Gilissen LP, Engels LG, et al. Pharmacokinetics of 6-mercaptopurine in patients with inflammatory bowel disease: implications for therapy. Ther Drug Monit. 06. 2004;26(3):311-8. [pmid: 15167634].
61 Dubinsky MC, Lamothe S, Yang HY, et al. Pharmacogenomics and metabolite measurement for 6-mercaptopurine therapy in inflammatory bowel disease. Gastroenterol. 04. 2000;118(4):705-13.
62 Gearry RB, Roberts RL, Barclay ML, et al. Lack of association between the ITPA 94C>A polymorphism and adverse effects from azathioprine. Pharmacogenetics. 11. 2004;14(11):779-81. [pmid: 15564886].
63 Hibi T, Naganuma M, Kitahora T, et al. Low-dose azathioprine is effective and safe for maintenance of remission in patients with ulcerative colitis.[see comment]. J Gastroenterol. 2003;38(8):740-6. [pmid: 14505127].
64 Ishioka S, Hiyama K, Sato H, et al. Thiopurine methyltransferase genotype and the toxicity of azathioprine in Japanese.[see comment]. Internal Med. 12. 1999;38(12):944-7. [pmid: 10628931].
65 Kim JH, Cheon JH, Hong SS, et al. Can we predict highly frequent myelotoxicity during azathioprine/6-mercaptopurine treatment in Korean patients with inflammatory bowel disease by thiopurine methyltransferase genotyping and phenotyping or inosine triphosphate pyrophosphatase genotyping? A multicenter study. Gastroenterol. 2008;134.
66 Jojic N, Urosevic J, Bojic B, et al. Determination of thiopurine methyltransferase genotype in the patients with inflammatory bowel disease before and during azathioprine therapy. Arch Gastroenterohepatol. 2003;22(1–2):5-9.
67 Jun JB, Cho DY, Kang C, et al. Thiopurine S-methyltransferase polymorphisms and the relationship between the mutant alleles and the adverse effects in systemic lupus erythematosus patients taking azathioprine. Clinical & Experimental Rheumatology. 11. 2005;23(6):873-6. [pmid: 16396707].
68 Lopez AJ, Schwab M, Witt H, et al. The impact of genetic variants in TPMT, ITPA, MTHFR, SPINK1 and PRSS1 on azathioprine-induced pancreatitis. Gastroenterol. 2006;130.
69 Marinaki AM, Ansari A, Duley JA, et al. Adverse drug reactions to azathioprine therapy are associated with polymorphism in the gene encoding inosine triphosphate pyrophosphatase (ITPase). Pharmacogenetics. 03. 2004;14(3):181-7. [pmid: 15167706].
70 Palmieri O, Latiano A, Bossa F, et al. Sequential evaluation of thiopurine methyltransferase, inosine triphosphate pyrophosphatase, and HPRT1 genes polymorphisms to explain thiopurines' toxicity and efficacy.[erratum appears in Aliment Pharmacol Ther. 2007 Sep 15;26(6):968]. Aliment Pharmacol Ther. 09. 1. 2007;26(5):737-45. [pmid: 17697207].
71 Reuther LO, Sonne J, Larsen NE, et al. Pharmacological monitoring of azathioprine therapy. Scand J Gastroenterol Suppl. 09. 2003;38(9):972-7.
72 Schmeling H, Abdelhaleem M, Benseler S, et al. Role of TPMT genotyping and azathioprine metabolites in predicting toxicity of azathioprine in PSLE patients. Arthritis Rheum. 2007;56(12):4265-6.
73 Seddik M, Texier F, Ferrari N, et al. Thiopurine S-Methyltransferase Genotyping Does Not Predict Azathioprine-Induced Myelosuppression in Crohn'S Disease. Dig Dis Week Abstr Itinerary Planner. 2003;2003.
74 Stocco G, Martelossi S, Barabino A, et al. Glutathione-S-transferase genotypes and the adverse effects of azathioprine in young patients with inflammatory bowel disease. Inflamm Bowel Dis. 01. 2007;13(1):57-64. [pmid: 17206640].
75 Tamori A, Shinzaki M, Kosaka S, et al. Thiopurine S-methyltransferase gene polymorphism in Japanese patients with autoimmune liver diseases. Liver Internat. 02. 2007;27(1):95-100.
76 Tani C, Mosca M, Colucci R, et al. Genetic polymorphisms of thiopurine S-methyltransferase in a cohort of patients with systemic autoimmune diseases. Clin Experiment Rheum. 2009;27(2):321-4.
77 van Dieren J, van Vuuren H, Kuipers E, et al. Heterozygous polymorphisms in the genes encoding ITPA and TPMT*3A are not predictive for the development of adverse effects of azathioprine treatment in IBD patients. Gastroenterol. 2005;128.
78 Zelinkova Z, Derijks LJ, Stokkers PC, et al. Inosine triphosphate pyrophosphatase and thiopurine s-methyltransferase genotypes relationship to azathioprine-induced myelosuppression. Clin Gastroenterol Hepatol. 01. 2006;4(1):44-9. [pmid: 16431304].
79 Kolorz M, Bartosova L, Hosek J, et al. Importance of thiopurine S-methyltransferase gene polymorphisms for prediction of azathioprine toxicity. Neuroendocrinol Let. 2009;30(Suppl 1):137-42. [pmid: 20027160].
80 Hagaman JT, Kinder BW, Eckman MH. Thiopurine S-methyltranferase testing in idiopathic pulmonary fibrosis: A pharmacogenetic cost-effectiveness analysis. Lung. 2010;188(2):125-32. [pmid: 20066544].
81 Gurwitz D, Rodriguez-Antona C, Payne K, et al. Improving pharmacovigilance in Europe: TPMT genotyping and phenotyping in the UK and Spain. Eur J Hum Genet. 08. 2009;17(8):991-8. [pmid: 19223932].
82 Compagni A, Bartoli S, Buehrlen B, et al. Avoiding adverse drug reactions by pharmacogenetic testing: a systematic review of the economic evidence in the case of TPMT and AZA-induced side effects. [Review] [32 refs]. Int J Technol Assess Health Care. 2008;24(3):294-302. [pmid: 18601797].
83 Sayani FA, Prosser C, Bailey RJ, et al. Thiopurine methyltransferase enzyme activity determination before treatment of inflammatory bowel disease with azathioprine: effect on cost and adverse events. Can J Gastroenterol. 03. 2005;19(3):147-51. [pmid: 15776134].
84 Priest VL, Begg EJ, Gardiner SJ, et al. Pharmacoeconomic analyses of azathioprine, methotrexate and prospective pharmacogenetic testing for the management of inflammatory bowel disease. Pharmacoeconomics. 2006;24(8):767-81. [pmid: 16898847].
85 Dubinsky MC, Reyes E, Ofman J, et al. A cost-effectiveness analysis of alternative disease management strategies in patients with Crohn's disease treated with azathioprine or 6-mercaptopurine. Am J Gastroenterol. 10. 2005;100(10):2239-47. [pmid: 16181376].
86 Winter J, Walker A, Shapiro D, et al. Cost-effectiveness of thiopurine methyltransferase genotype screening in patients about to commence azathioprine therapy for treatment of inflammatory bowel disease.[see comment]. Aliment Pharmacol Ther. 09. 15. 2004;20(6):593-9. [pmid: 15352906].
87 Oh KT, Anis AH, Bae SC. Pharmacoeconomic analysis of thiopurine methyltransferase polymorphism screening by polymerase chain reaction for treatment with azathioprine in Korea. Rheumatology. 02. 2004;43(2):156-63. [pmid: 12923290].
88 Marra CA, Esdaile JM, Anis AH. Practical pharmacogenetics: the cost effectiveness of screening for thiopurine s-methyltransferase polymorphisms in patients with rheumatological conditions treated with azathioprine. J Rheum. 12. 2002;29(12):2507-12. [pmid: 12465143].
89 Tavadia SM, Mydlarski PR, Reis MD, et al. Screening for azathioprine toxicity: a pharmacoeconomic analysis based on a target case. J Am Acad Dermatol. 04. 2000;42(4):628-32. [pmid: 10727309].
90 Prashker MJ, Meenan RF. The total costs of drug therapy for rheumatoid arthritis. A model based on costs of drug, monitoring, and toxicity. Arthritis Rheum. 03. 1995;38(3):318-25. [pmid: 7880185].