# Data extraction and related forms

## Key Questions 1a and 1b

Pre-analytical requirements for enzymatic measurement of TPMT and determination of TPMT allelic polymorphisms; and

Within and between laboratory precision and reproducibility of enzymatic measurement of TPMT and determination of TPMT allelic polymorphisms

Data element | Comments, coding for data extraction
Ref id
First author, year
Companion ref id | If applicable
Contains information about (select all that apply) | 1= pre-analytic requirement; 2 = post-analytic requirement, 3 = within laboratory precision and reproducibility, 4 = between laboratory precision and reproducibility
Full or partial industry funding | 0 = no, 1 = yes, 2 = not reported
Study region | 1= North America; 2 = Europe, 3 = Central and South America, 4 = sub Saharan Africa, 5 = Middle East and North Africa, 6 = South Asia, 7 = Asia, 9 = Oceania, 10 = 1+ 2, 11 = mixed/others, 12 = not reported
Summary description of TPMT activity assay
Summary description of TPMT genotyping assay
Summary of pertinent paper (capture as much as possible in as few words)
Study limitations
If not eligible for extraction, provide reasons

Abbreviations: Ref id = unique reference identification number; TPMT = thiopurine methyltransferase

## Key question 1c

Diagnostic sensitivity and specificity of TPMT allelic polymorphism measurement compared to the measurement of TPMT enzymatic activity

### 1 General information for key question 1c

Data element | Comments, coding
Ref id
First author, year
Companion ref id
Author contacted | 1 = yes, 0 = no
Full or partial industry funding | 0 = no, 1= yes, 2 = not reported
Region of participants residence | 1= North America; 2 = Europe, 3 = central and South America, 4 = sub Saharan Africa, 5 = Middle East and north Africa, 6 = South Asia, 7 = Asia, 9 = Oceania, 10 = 1+ 2, 11 = mixed others, 12 = not reported
Diagnostic study design | 1 = cross-sectional, 2 = case-control, 3 = prospective observational (including cohort), 4 = RCT, 5 = can't tell, 6 = other (specify)
Is enzymatic activity assay the reference/gold standard? | 1 = yes, 0 = No
Enzymatic activity assay: testing method? | 1 = Radioassay, 2 = HPLC, 3 = other (name the method), 4 = NR
Enzymatic activity assay: manufacturer?
Enzymatic activity: categories? | 1 = high, normal, intermediate, low, absent; 2 = high, normal, intermediate, low/absent; 3 = high/normal, intermediate, low, absent; 4 = high/normal, intermediate, low/absent; 5 = other (specify)
Enzymatic activity: cut off values? | specify different cut-offs or state NR
Genotyping: method | specify (e.g. RFLP, RT-PCR (probe hybridization or fluorescence), INVADER-PCR etc.) 1= PCR, 2 = pyrosequencing, 3 = other
Source of DNA for genotyping? | specify
Number of SNPs genotyped
Specify genotyped SNPs
Setting | 1= inpatient, 2 = outpatient primary care, 3 = outpatient specialty clinic, 4 = NR or can't tell
Participants | (a few words to describe the study population)
Participants, summary inclusion/exclusion criteria
Underlying disease (s) | including severity
Thiopurine treatment | 0= no; 1 = AZA, 2 = 6-MP, 3 = mixed thipurines, 4 = other, 5 = NR
Concomitant treatment potentially affecting TPMT activity | 1 = no, 2 = allopurinol, 3 = 5-ASA (mesalazine/mesalamine/sulphasalazine, olsalazine), 4 = furosemide/frusemide, 5 = NSAID, 6 = other (specify), 7 = NR
Age group | 1 = adults (>=16) only, 2 = children only (<16), 3 = adolescence only, 4 = mixed, 5 = not sure/NR
Age in years | mean or median or range
Females %
Caucasians %
African descent %
Hispanic %
Asians %
Other % | specify race and % of participants
This report also has relevant subgroup data of genotyping and phenotyping results | specify subgroups
Applicability based on population characteristics and testing methodology | 1 = applicable, 2 = not applicable (explain why), 3= questionable applicability (explain why)

Abbreviations: 6-MP = 6-mercaptopurine; ASA = acetylsalicylic acid or aspirin ; AZA = azathioprine; NR = not reported; NSAID = nonsteroidal anti-inflammatory drug; Ref id = unique reference identification number; TPMT = thiopurine methyltransferase

### 2 Quantitative evidence for key question 1c

Data element | Comments, coding for data extraction
Ref id
First author, year
Total number included in the study
Dropouts and withdrawals or untested
Activity assay: number of patients with non-interpretable test results
Genotyping: number of patients with non-interpretable test results
SNPs tested | Specify SNPs
First comparison
Genotypes | Heterozygous or homozygous for variant(s)/wild type
Normal or hyperactivity (or controls) | Numbers of participants with particular enzyme activity, with genotype
Intermediate or low/absent activity (or cases) | Numbers of participants with particular enzyme activity, with genotype
Second comparison
Genotype | Homozygous for variant(s)/Wild type or heterozygous for variants
Normal/hyperactivity/intermediate activity (or controls) | Numbers of participants with particular enzyme activity, with genotype
Low/absent activity (or cases) | Numbers of participants with particular enzyme activity, with genotype
Number of allele specific subgroups

Abbreviations: Ref id = unique reference identification number; TPMT = thiopurine methyltransferase

### 3 Quality assessment for key question 1c

Data element | Comments, coding for data extraction
Ref id
First author, year
Is the spectrum of patients representative of those with one or more chronic autoimmune disease in terms of eligibility criteria, demographics, disease severity? | 1 = yes, 0 = no, 2 = unclear
Clearly describes I/E criteria? | 1 = yes, 0 = no, 2 = unclear
Was the reference test (activity assay) likely to correctly identify enzymatic activity? | 1 = yes, 0 = no, 2 = unclear
Did the whole or a random sample of patients receive TPMT activity test? | 1 = yes, 0 = no, 2 = unclear
Was the TPMT activity test administered regardless of genotyping results? | 1 = yes, 0 = no, 2 = unclear
Were the TPMT activity and genotyping tests independent of each other? | 1 = yes, 0 = no, 2 = unclear
Was the genotyping method clearly described for replication? | 1 = yes, 0 = no, 2 = unclear
Was the activity assay clearly described for replication? | 1 = yes, 0 = no, 2 = unclear
Activity test results were not interpreted with prior knowledge of genotyping results? | 1 = yes, 0 = no, 2 = unclear
Genotyping results were not interpreted with prior knowledge of enzymatic activity? | 1 = yes, 0 = no, 2 = unclear
Were the clinical data availability before testing was undertaken similar to that in usual practice setting in which the testing will be performed? | 1 = yes, 0 = no, 2 = unclear
Were non-interpretable or equivocal test results reported? | 1 = yes, 0 = no, 2 = unclear
Were withdrawals from the study explained? | 1 = yes, 0 = no, 2 = unclear
Was deviation from Hardy-Weinberg equilibrium reported? | 1 = yes, 0 = no, 2 = unclear
Reviewer’s overall risk of bias assessment | 1 = Good; 2 = Fair, 3 = Poor
Reason for overall risk of bias assessment (explain why good if good, explain why not good if fair or poor) | specify

Abbreviations: I/E = inclusion/exclusion; Ref id = unique reference identification number.

## Laboratory Survey Introductory Letter

Sent by email attachment, on Ottawa Health Research Institute letterhead

DATE

Dear Dr. X,

The University of Ottawa Evidence-based Practice Center (EPC) is conducting a systematic review on the assessment of Thiopurine Methyltransferase (TPMT) in patients prescribed Azathiopurine or other Thiopurine-based Drugs.

In addition to obtaining relevant data from the literature, we are conducting a survey to obtain specific data from laboratories that are involved in measuring TPMT. We are very interested in gathering data from your organization and invite you to participate in our survey. We would be happy to share with you the results of the survey as well as the final report. All data from the survey will be pooled ensuring anonymity. No organization will be identified in the report. The survey should take no more than 15-20 minutes to complete and we will give you three weeks to complete it. Please note all data will be housed for 15 years after termination of the study.

At this time we’d like to inquire into whether you are interested in participating in the survey. If so, we would greatly appreciate a response on this matter by DATE.

In your response, please include the proper name of your organization as well as the contact person/details.

Name of Organization: ________________________________________________

Contact name and details: ______________________________________________

If you have any questions about your rights as a research participant, you may contact the Board Chairman at 613-798-5555 ext 14902.

Sincerely,

Sophia Tsouros

Research Coordinator, University of Ottawa Evidence-Based Practice Centre

Clinical Epidemiology Program, Ottawa Hospital Research Institute

501 Smyth Road W0575

Box 208

Ottawa, Ontario, CANADA K1H 8L6

Ph: 613.737.8899 ext. 73920

Fax: 613.737.8781

Email: stsouros@ohri.ca

On behalf of Dr. Ronald Booth, Clinical Chemist, Ottawa Hospital Research Institute, Clinical Lead, TPMT review and Dr. David Moher, Director of EPC

## Survey for “Thiopurine Methyltransferase” Laboratories

The University of Ottawa Evidence-based Practice Center is conducting a systematic review on assessment of Thiopurine Methyltransferase (TPMT) in patients prescribed Azathiopurine or other Thiopurine-based Drugs.

In addition to obtaining relevant data from the literature, we are conducting a survey to obtain specific data from laboratories that are involved in measuring TPMT. We are very interested in gathering data from your organization and invite you to participate in our survey. We would be happy to share with you the results of the survey as well as the final report. All data from the survey will be pooled ensuring anonymity. No organization will be identified in the report. The survey should take no more than 15-20 minutes to complete.

Name of Organization (text box)

Contact name (text box)

1. Does your laboratory perform analysis of Thiopurine Methyltransferase (TPMT) in-house?
  - No
  - Genotyping only
  - Phenotyping (Enzymatic analysis) only
  - Both Genotyping and Phenotyping
    a. If no, do you refer specimens out for analysis of TPMT?
      Yes
      No
    b. If yes to 1a, where do you send your specimens for analysis of TPMT, and what type of analysis is done (genotyping or phenotyping)?
      (Text box)
2. What method is used for analysis of TPMT?
  a. Enzymatic assay - please select detection method (select all that apply):
    i. Radiometric,
    ii. HPLC,
    iii. Mass Spec.,
    iv. Other (please specify) (Text box)
  b. Genetic analysis - please select method (select all that apply):
    i. Sequencing
    ii. PCR/RFLP
    iii. Real Time PCR
    iv. Site directed PCR (please indicate mutations screened for)
    v. Other (please specify) (Text box)
  c. If mutation specific genetic analysis is performed please indicate all alleles targeted (select all that apply):
    i. TPMT*2
    ii. TPMT*3A
    iii. TPMT*3B
    iv. TPMT*3C
    v. Other (please list) (Text box)
3. What is your yearly TPMT testing volume (indicate separately for both genotyping and phenotyping if applicable)? (Text box)
4. What is the preferred specimen type for analysis
  a. Enzymatic analysis
    i. Not applicable
    ii. EDTA whole blood
    iii. Heparinized whole blood
    iv. Other (please indicate) (Text box)
  b. Genotyping
    i. Not applicable
    ii. EDTA whole blood
    iii. Heparinized whole blood
    iv. Other (please indicate) (Text box)
5. What are the pre-analytical requirements for analysis
  a. Specimen stability prior to analysis
    i. Enzymatic analysis
      1. Not applicable
      2. Specimen stability time (please indicate number of hours) (Text box)
      3. Storage temperature (room temperature, 4 C, -20 C, or -70 C) (Text box)
    ii. Genotyping
      1. Not applicable
      2. Specimen stability time (please indicate number of hours) (Text box)
      3. Storage temperature (room temperature, 4 C, -20 C, or -70 C) (Text box)
  b. Do you require a list of medications the patient is currently taking?
    i. Yes
    ii. No
6. What are the quality control results for:
  a. Enzymatic analysis
    i. Coefficient of Variation
      1. Within run (Text box)
      2. Between runs (Text box)
  b. Genotyping
    i. Percent concordance with another genotyping method and/or genotyping standards from an external source. Please indicate the percentage the comparator genotyping methods and the basis of the comparison. (Text box)
  c. Enzymatic analysis in comparison with genotyping
    i. Percent concordance between TPMT phenotyping and for each range of enzymatic activity reported by your laboratory. (Text box)
7. Do you participate in an External Quality Assurance (EQA) program? (Please indicate details of the program) (Text box)
8. What type of quality control is performed?
  a. In-house (patient pool or other – please indicate) (Text box)
  b. Commercial (please indicate supplier) (Text box)
  c. Please indicate number of quality control levels (1, 2, 3, more) and quality control frequency (per-run, every day, multiple per day) (Text box)
9. Reporting of results
  a. Are abnormal results called to the physician
    i. No
    ii. Yes (under what circumstances) (Textbox)
  b. Please indicate your reference intervals for normal (homozygous wild type), heterozygote, and deficient as well as units of measure. (Text box)
  c. How was your reference interval determined?
    i. Correlation with known homozygous normal patients
    ii. Other (please explain) (Text box)
  d. Do you highlight suspected heterozygous patients when analyzed by enzymatic assay
    i. No
    ii. Yes (under what circumstances) (Text box)
10. Please provide your expected turn around time of the laboratory testing you provide. (Text box)
11. Please provide details of the charges associated with laboratory testing in your native currency. (Please specify currency)
  a. TPMT enzymatic activity test (Text box)
  b. TPMT genotyping(Text box)

## Key Question (2), 3a, 3b

(No studies were identified to answer Key Question 2)

TPMT status to guide therapy - Cohort studies

Data element | Comments, coding for data extraction
Ref id
First author, Year
Study site and setting
Full or partial industry funding | 0 = no, 1= yes, 2 = not reported
Total number of participants included in the study
Describe population characteristics and setting | (a few words to describe the study population in terms of age, ethnicity, underlying diseases and their severity, and practice setting)
Followup period
Number of person weeks by groups
Number lost to followup
Intervention group description (including type of TMPT testing and treatment modification). n | Intervention group is the group which had TPMT pre-testing followed by thiopurine treatment adjustment
Control group description (no testing and no treatment modification [underlined: OR] testing but no treatment modification based on its results). n | Control group had no treatment adjustment based on TPMT pre-testing
Treatment and dosage intervention group | 0= no; 1 = AZA, 2 = 6-MP, 3 = mixed thiopurines, 4 = other, 5 = NR
Treatment and dosage in the control | 0= no; 1 = AZA, 2 = 6-MP, 3 = mixed thipurines, 4 = other, 5 = NR
Outcome, and definition | mortality, SAE, WDAE, all infections, sepsis, hospitalization, ICU admission, myelotoxicity, leukopenia, neutropenia
n experiencing the outcome
Confounding factors controlled for | state factors
Crude RR (intervention/control)
Adjusted RR (adjusted for?) (intervention/control)
Risk difference
Proportion of those with outcome of interest in the intervention group n/N | N = total number in the group
Proportion of those with the outcome of interest in the control group, n/N | N = total number in the group
Were investigators and participants blinded to testing? | 0 = no, 1 = yes, 2 = unclear
Was there a blinded assessment of outcomes? | 0 = no, 1 = yes, 2 = unclear
Were groups similar in characteristics at baseline | 0 = not similar, 1 = similar, 2 = unclear
Were outcomes adequately described? | 1 = reasonably adequately, 0 = inadequately, 2 = unclear
Was there an intention to treat analysis? | 0= no, 1 = yes, 2 =unclear
Is there a conflict of interest? | 1 = yes, 2 = likely, 3 = unlikely
Was there a high loss to follow-up or important differential loss to follow-up between groups? | 0 = no, 1 = yes, 2 = unclear
Is the sample size adequate? | 0 = no, 1 = yes, 2 = unclear
Was the selection of participants unlikely to be biased? (e.g. inception cohort or method to avoid selection bias) | 0 = no, 1 = yes, 2 = unclear
Were methods to control confounding (e.g. matching, restriction to subgroups, analytic methods of stratification, propensity scores etc.) employed? | 0 = no, 1 = yes, 2 = unclear
Were the method of TPMT testing (as applicable, e.g. genotyping, or phenotyping or both) appropriate? | 0 = no, 1 = yes, 2 = unclear
Reviewer’s overall risk of bias assessment for the study | 1 = Good; 2 = Fair, 3 = Poor
Reason for overall risk of bias assessment (explain why good if good, explain why not good if fair or poor) | specify
Applicability based on population characteristics and testing methodology | 1 = applicable, 0 = not applicable (explain why), 2 questionable applicability (explain why)

Abbreviations: 6-MP = 6-mercaptopurine; AZA = azathioprine; ICU = intensive care unit; n = number with characteristic of interest; N = total number in group or trial or study; NR = not reported; RR = relative risk; Ref id = unique reference identification number.

## Key question 3c - phenotyping

Association between TPMT status as determined by phenotyping, and adverse events

Data element | Comments, coding for data extraction
Ref id
First author, year
Thiopurine treatment tailored according to TPMT genotype? | 0 = no, 1 = yes (if yes do not data extract the study on this sheet. That is, the study does not qualify for Q3c)
Companion ref id | If applicable
Author contacted | 1 = yes, 0 = no
Full or partial industry funding | 0 = no, 1= yes, 2 = not reported
Region of participants residence | 1= North America; 2 = Europe, 3 = central and South America, 4 = sub Saharan Africa, 5 = Middle East and north Africa, 6 = South Asia, 7 = Asia, 9 = Oceania, 10 = 1+ 2, 11 = mixed others, 12 = not reported
Setting | 1= inpatient, 2 = outpatient primary care, 3 = outpatient specialty clinic, 4 = NR or can’t tell
Participants | (a few words to describe the study population)
Participants, summary inclusion/exclusion criteria summary
Underlying disease(s) | including severity
Thiopurine treatment following TPMT testing? | 0= no; 1 = AZA, 2 = 6-MP, 3 = mixed thipurines, 4 = other, 5 = NR
Concomitant treatment affecting TPMT activity | 1 = no, 2 = allopurinol, 3 = 5-ASA (mesalazine/mesalamine/sulphasalazine, olsalazine), 4 = furosemide/frusemide, 5 = NSAID, 6 = other (specify), 7 = NR
Drug dosage | e.g. X mg/day
Age group | 1 = adults (>=16) only, 2 = children only (<16), 3 = adolescence only, 4 = mixed, 5 = not sure/NR
Age in years | mean or median or range
Females %
Caucasians %
African descent %
Hispanic %
Asians %
Other % | specify race and % of participants
This report also has relevant subgroup data for | specify subgroup
Study duration, or duration of followup for outcome assessment | weeks
Describe TPMT activity assay | 1 = RA; 2 = Mass spectrometry; 3 = HPLC, 4 = Other (specify)
Cut of, or range, for TPMT high activity | state NR if not reported
Cut of, or range, for TPMT normal activity | state NR if not reported
Cut of, or range, for TPMT intermediate activity | state NR if not reported
Cut of, or range, for TPMT low/absent activity | state NR if not reported
Study design | 1 = cohort (retrospective or prospective), 2 = case-control, 3 = cross-sectional, 4 = other (specify)
In this report, was there clearly no biased assessment of outcomes and/or phenotyping results based on a prior knowledge of each other? | 1 = yes, 2 = no, 3 = unclear
Were the groups similar at baseline? | 1 = yes, 2 = no, 3 = unclear
Were outcomes described adequately? | 1 = yes, 2 = no, 3 = unclear
Was there an intention to treat analysis? | 0= no, 1 = yes, 2 = can’t tell
Is there a potential for financial conflict of interest? | 1 = yes, 2 = no, 3 = unclear
Was there a high loss to follow- up or important differential loss to follow-up between groups? | 1 = yes, 2 = no, 3 = unclear
Is the sample size adequate? | 1 = yes, 2 = no, 3 = unclear
Was the selection of participants unlikely to be biased? (e.g. inception cohort or method to avoid selection bias) | 1 = yes, 2 = no, 3 = unclear
Were methods to control confounding (e.g. matching, restriction to subgroups, analytic methods of stratification, propensity scores etc.) employed? | 1 = yes, 2 = no, 3 = unclear
Were the method of TPMT testing (as applicable, e.g. genotyping, or phenotyping or both) appropriate? | 1 = yes, 2 = no, 3 = unclear
Reviewers overall risk of bias assessment for the study | 1 = Good; 2 = Fair, 3 = Poor
Reason for overall risk of bias assessment (explain why good if good, explain why not good if fair or poor) | specify
Applicability based on population characteristics and testing methodology | 1 = applicable, 2 = not applicable (explain why), 3= questionable applicability (explain why)
N total recruited (i.e. included in the study)
N total analyzed
Dichotomous Outcome | 1 = mortality, 2 = any infection (including sepsis), 3 = sepsis, 4 = hospitalization, 5 = ICU admission, 6 = WDAE, 7 = SAE, 8 = HQoL (describe instrument), 9 = hepatitis, 10 = pancreatitis, 11 = myelotoxicity, 12 = leukopenia, 13 = neutropenia, 14 = anemia, 15 = thrombocytopenia, 16 = number in need of thiopurine dose reduction, 17 = number in need of switching to another immunomodulating treatment
Definition (or details) of dichotomous outcomes where applicable
Continuous outcomes | 1 = any infection (including sepsis), 2 = sepsis, 3 = HQoL (describe instrument), 4 = hepatitis, 4 = pancreatitis, 6 = myelotoxicity, 7 = leukopenia, 8 = neutropenia, 9 = anemia, 10 = thrombocytopenia, 11 = number in need of thiopurine dose reduction, 12 = number in need of switching to another immunomodulating treatment
Definition (or details) of continuous outcomes where applicable
Low or absent activity: n with events
Low or absent activity: n without events
Intermediate activity: n with events
Intermediate activity: n without events
Normal activity: n with events
Normal activity: n without events
Continuous outcome mean (specify whether its is mean change, post treatment mean, or percentage mean change) with unit
Continuous outcome -- applicable group | e.g. all homozygotes or all heterozygotes etc.
Measure of dispersion (SD or SE)
N analyzed for the group
If not eligible for extraction, provide reasons here

Abbreviations: HPLC = high performance liquid chromatography; HQoL = health related quality of life; ICU = intensive care unit; n = number with characteristic of interest; N = total number in group or trial or study; NR = not reported; RA = radiolabel assay; Ref id = unique reference identification number; SD = standard deviation; SE = standard error; SEA = serious adverse events; TPMT = thiopurine methyltransferase; WDAE = withdrawal due to adverse events.

## Key question 3c - genotyping

Association between TPMT status as determined by genotyping, and adverse events

Data element | Comments, coding for data extraction
Ref id
First Author, year
Thiopurine treatment tailored according to TPMT genotype? | 0 = no, 1 = yes (if yes do not data extract the study on this sheet. That is, the study does not qualify for Q3c
Companion ref id (if applicable)
Author contacted? | 1 = yes, 0 = no
Full or partial industry funding | 0 = no, 1= yes, 2 = not reported
Region of participants residence | 1= North America; 2 = Europe, 3 = central and South America, 4 = sub Saharan Africa, 5 = Middle East and north Africa, 6 = South Asia, 7 = Asia, 9 = Oceania, 10 = 1+ 2, 11 = mixed others, 12 = not reported
Setting | 1= inpatient, 2 = outpatient primary care, 3 = outpatient specialty clinic, 4 = NR or can’t tell
Participants | (a few words to describe the study population)
Participants, summary inclusion/exclusion criteria summary
Underlying disease (s) | including severity
Type of thiopurine treatment? | 0= no; 1 = AZA, 2 = 6-MP, 3 = mixed thiopurines, 4 = other, 5 = NR
Drug dosage | e.g. x mg/day
Concomitant treatment potentially affecting TPMT activity | 1 = no, 2 = allopurinol, 3 = 5-ASA (mesalazine/mesalamine/sulphasalazine, olsalazine), 4 = furosemide/frusemide, 5 = NSAID, 6 = other (specify), 7 = NR
Age group | 1 = adults (>=16) only, 2 = children only (<16), 3 = adolescence only, 4 = mixed, 5 = not sure/NR
Age in years | mean or median or range
Percentage females
Caucasians %
African descent %
Hispanic %
Asians %
Other % | specify race and % of participants
This report also has relevant subgroup data for | specify subgroup
Study duration, or duration of follow-up for outcome assessment | weeks
Describe genotyping assay | 1 pyrosequencing; 2 = PCR, 3 = other (specify)
Number of TPMT alleles tested
Specify TPMT Alleles tested
Study design | 1 = cohort (retrospective or prospective), 2 = case-control, 3 = cross-sectional, 4 = other (specify)
Were genotype groups comparable? | 1 = yes, 0 = no, 2 = unclear (Subjects should have been matched by ethno-geographic and ancestral origin and confounding variables (e.g. social indicators) or by clearly describing techniques of matching by genetic background to avoid confounding by population stratifications. If not, genomic control to test for patterns in unlinked markers should be undertaken (i.e. results were adjusted for additional genetic markers associated with ancestry in the population). Also, subjects should be matched for characteristics that are also likely to be genetically determined and also associated with the outcome of interest (e.g. weight). Consider control for clinical and other modifiers (e.g. diet and smoking) between genotypes)
Were participants enrolled in studies without prior knowledge of genotype? | 1 = yes, 0 = no, 2 = unclear
In this report, was there clearly no biased assessment of outcomes and/or genotyping results based on prior knowledge of each other? (i.e. blinded for outcomes and/or genotyping results) | 1 = yes, 0 = no, 2 = unclear
Was genotyping method described adequately? | 1 = yes, 0 = no, 2 = unclear (how samples were handled, what genotyping methods was used, any quality checks, rules set to say when genotyping results would be considered valid)
Was reliability of genotyping method established? | 1 = yes, 0 = no, 2 = unclear (i.e. reference to a paper where genotyping assay reliability was assessed or re-genotyping of all/random subset of samples)
Is the extent of ambiguous results due to genotyping error reported? | 1 = yes, 0 = no, 2 = unclear (i.e. reference to a paper where genotyping assay reliability was assessed or re-genotyping of all/random subset of samples)
Was Hardy-Weinberg equilibrium tested? | 1 = yes, 0 = no, 2 = unclear (in cohort studies, HWE should have been tested in the whole study population, but in the case-control in the controls only, which represent the general population)
Was gene-gene interaction assessed? | 1 = yes, 0 = no, 2 = unclear
Did studies assess compliance with thiopurine treatment (and correct for differences where applicable)? | 1 = yes, 0 = no, 2 = unclear
Did studies utilize different sources of DNA for all patients, introducing potential measurement bias? | 1 = yes, 0 = no, 2 = unclear
Was lost to followup reported? | 1 = yes, 0 = no, 2 = unclear
Was there possibility of survival bias? For example, hyper-normal population (older people, free of disease) can introduce survival bias | 1 = yes, 0 = no, 2 = unclear
Is there a potential for financial conflict of interest? | 1 = yes, 0 = no, 2 = unclear
Reviewers overall risk of bias assessment for the study | 1 = Good; 2 = Fair, 3 = Poor
Reason for overall risk of bias assessment (explain why good if good, explain why not good if fair or poor) | specify
Applicability based on population characteristics and testing methodology | 1 = applicable, 2 = not applicable (explain why), 3= questionable applicability (explain why)
N total recruited (i.e. included in the study)
N total analyzed
Dichotomous Outcome | 1 = mortality, 2 = any infection (including sepsis), 3 = sepsis, 4 = hospitalization, 5 = ICU admission, 6 = WDAE, 7 = SAE, 8 = HQoL (describe instrument), 9 = hepatitis, 10 = pancreatitis, 11 = myelotoxicity, 12 = leukopenia, 13 = neutropenia, 14 = anemia, 15 = thrombocytopenia, 16 = number in need of thiopurine dose reduction, 17 = number in need of switching to another immunomodulating treatment
Definition (or details) of outcomes where applicable
TPMT*2 homozygous: n with events
TPMT*2 homozygous: n without events
TPMT*2 heterozygous: n with events
TPMT*2 heterozygous: n without events
TPMT*3A homozygous: n with events
TPMT*3A homozygous: n without events
TPMT*3A heterozygous: n with events
TPMT*3A heterozygous: n without events
TPMT*3C homozygous: n with events
TPMT*3C homozygous: n without events
TPMT*3C heterozygous: n with events
TPMT*3C heterozygous: n without events
TPMT wild type: n with events
TPMT wild type: n without events
All homozygotes for TPMT allelic variant: n with events
All homozygotes for TPMT allelic variant: n without events
All heterozygotes for TPMT allelic variant: n with events
All heterozygotes for TPMT allelic variant: n without events
If not eligible for extraction, provide reasons here
Allele specific subgroups
Across alleles

Abbreviations: HPLC = high performance liquid chromatography; HQoL = health related quality of life; ICU = intensive care unit; n = number with characteristic of interest; N = total number in group or trial or study; NR = not reported; PCR = polymerase chain reaction; Ref id = unique reference identification number; SEA = serious adverse events; TPMT = thiopurine methyltransferase; WDAE = withdrawal due to adverse event

## Key Question 4

Costs of TPMT testing, costs of care, and costs of treating drug-associated complications

Data element | Comments, coding for data extraction
Ref id
First author, year
Companion ref id (if applicable)
Author contacted? | 1 = yes, 0 = no
Country
Type of Study | E.g. Cost-effectiveness analysis, cost analysis
Population Characteristics | E.g. type and severity of chronic autoimmune disease, ethnic and age distribution
Perspective
Costs of adverse events and care
Currency
Year of costing data
Source of cost data
Costing item | E.g. myelosuppression, ICU stay, etc.
Type of costing data | E.g. one time annual cost
Cost
Converted to USD 2008 (inflation and conversion rate) | Must use the PPP for this
Costs of testing
Currency | E.g. USD
Year of costing data
Source of cost data
Type of test
Costing details
Cost
Converted to USD 2008 (inflation and conversion rate)
Cost of treating drug-associated complications
Currency
Year of costing data
Source of cost data
Type of drug | e.g., AZA, 6-MP, AZA & 6-MP
Costing item | e.g., myelosuppression due to AZA
Type of costing data | E.g. one time annual cost
Cost | Denomination and year
Converted to USD 2008 (inflation and conversion rate) | Must use the PPP for this
Other costs reported in study?

Abbreviations: AZA = azathioprine; 6-MP = 6-mercaptopurine; ICU = intensive care unit; PPP = purchasing power parities and the consumer price index, as described in the methods; Ref id = unique reference identification number; TPMT = thiopurine methyltransferase; USD = United States dollars