# Exact Search Strings

## Ovid MEDLINE(R) 1950 to May Week 3 2010

1. (TPMT* or thiopurine methyltransferase* or thiopurine s-methyltransferase* or thiopurine methyl-transferase* or thiopurine s-methyl-transferase* or Thiopurinemethyltransferase*).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
2. animal/
3. human/
4. 2 not (2 and 3)
5. 1 not 4

## EMBASE 1980 to 2010 Week 21

1. exp Thiopurine Methyltransferase/
2. (TPMT* or thiopurine methyltransferase* or thiopurine s-methyltransferase* or thiopurine methyl-transferase* or thiopurine s-methyl-transferase* or Thiopurinemethyltransferase*).mp. [mp=title, abstract, subject headings, heading word, drug trade name, original title, device manufacturer, drug manufacturer name]
3. 1 or 2
4. human.sh.
5. nonhuman.sh.
6. animal.sh. (18273)
7. animal experiment.sh.
8. or/5–7
9. 8 not (4 and 8)
10. 3 not 9

## Central (CLIB 2009 2)

(Thiopurine Methyltransferase*):ti,ab,kw or (TPMT* OR Thiopurinemethyltransferase*):ti,ab,kw or (thiopurine s-methyltransferase*):ti,ab,kw or (thiopurine methyl-transferase*):ti,ab,kw or (thiopurine s-methyl-transferase*):ti,ab,kw

## Ovid Healthstar 1966 to April 2010

1. (TPMT* or thiopurine methyltransferase* or thiopurine s-methyltransferase* or thiopurine methyl-transferase* or thiopurine s-methyl-transferase* or Thiopurinemethyltransferase*).mp.
2. animal/
3. human/
4. 2 not (2 and 3)
5. 1 not 4

## Genetic Abstracts. May 7 2009

Query: KW=(TPMT* OR thiopurine methyltransferase* OR thiopurine s-methyltransferase* OR thiopurine methyl-transferase* OR thiopurine s-methyl-transferase* OR Thiopurinemethyltransferase*) OR TI=(TPMT* OR thiopurine methyltransferase* OR thiopurine s-methyltransferase* OR thiopurine methyl-transferase* OR thiopurine s-methyl-transferase* OR Thiopurinemethyltransferase*) OR AB=(TPMT* OR thiopurine methyltransferase* OR thiopurine s-methyltransferase* OR thiopurine methyl-transferase* OR thiopurine s-methyl-transferase* OR Thiopurinemethyltransferase*)OR DE=(TPMT* OR thiopurine methyltransferase* OR thiopurine s-methyltransferase* OR thiopurine methyl-transferase* OR thiopurine s-methyl-transferase* OR Thiopurinemethyltransferase*)

## BioSYS May 5 2009

# 1 Topic=(TPMT* OR thiopurine methyltransferase* OR thiopurine s-methyltransferase* OR thiopurine methyl-transferase* OR thiopurine s-methyl-transferase* OR Thiopurinemethyltransferase*) OR Title=(TPMT* OR thiopurine methyltransferase* OR thiopurine s-methyltransferase* OR thiopurine methyl-transferase* OR thiopurine s-methyl-transferase* OR Thiopurinemethyltransferase*) Databases=PREVIEWS Timespan=All Years
# 2 DE=(TPMT* OR thiopurine methyltransferase* OR thiopurine s-methyltransferase* OR thiopurine methyl-transferase* OR thiopurine s-methyl-transferase* OR Thiopurinemethyltransferase*) Databases=PREVIEWS Timespan=All Years
# 3 #2 OR #1 Databases=PREVIEWS Timespan=All Years
# 4 TS=(econom* or cost or costs or costly or costing or costed or cost-benefit* or price or prices or pricing or priced or discount or discounts or discounted or discounting or expenditure or expenditures or budget* or afford* or pharmacoeconomic* or pharmacoeconomic*) Databases=PREVIEWS Timespan=All Years
# 5 TI=(econom* or cost or costs or costly or costing or costed or cost-benefit* or price or prices or pricing or priced or discount or discounts or discounted or discounting or expenditure or expenditures or budget* or afford* or pharmacoeconomic* or pharmaco-economic*) Databases=PREVIEWS Timespan=All Years
# 6 DE=(econom* or cost or costs or costly or costing or costed or cost-benefit* or price or prices or pricing or priced or discount or discounts or discounted or discounting or expenditure or expenditures or budget* or afford* or pharmacoeconomic* or pharmaco-economic*) Databases=PREVIEWS Timespan=All Years
# 7 TI=(markov or markow or monte carlo) Databases=PREVIEWS Timespan=All Years
# 8 TI=(markov or markow or monte carlo) Databases=PREVIEWS Timespan=All Years
# 9 DE=(markov or markow or monte carlo) Databases=PREVIEWS Timespan=All Years
# 10 TS=sensitivity analys* Databases=PREVIEWS Timespan=All Years
# 11 TI=sensitivity analys* Databases=PREVIEWS Timespan=All Years
# 12 DE=sensitivity analys* Databases=PREVIEWS Timespan=All Years
# 13 TS=quality adjusted life Databases=PREVIEWS Timespan=All Years
# 14 TI=quality adjusted life Databases=PREVIEWS Timespan=All Years
# 15 DE=quality adjusted life Databases=PREVIEWS Timespan=All Years
# 16 TS=CE analys?s Databases=PREVIEWS Timespan=All Years
# 17 TI=CE analys?s Databases=PREVIEWS Timespan=All Years
# 18 Databases=PREVIEWS Timespan=All Years
# 19 TS=(decision tree* or decision analy* or decision model*) Databases=PREVIEWS Timespan=All Years
# 20 TI=(decision tree* or decision analy* or decision model*) Databases=PREVIEWS Timespan=All Years
# 21 DE=(decision tree* or decision analy* or decision model*) Databases=PREVIEWS Timespan=All Years
# 22 TS=“quality of life” Databases=PREVIEWS Timespan=All Years
# 23 TI=“quality of life” Databases=PREVIEWS Timespan=All Years
# 24 DE=“quality of life” Databases=PREVIEWS Timespan=All Years
# 25 TS=“willingness to pay” Databases=PREVIEWS Timespan=All Years
# 26 TI=“willingness to pay” Databases=PREVIEWS Timespan=All Years
# 27 DE=“willingness to pay” Databases=PREVIEWS Timespan=All Years
# 28 Major Concepts=(Economics) Databases=PREVIEWS Timespan=All Years
# 29 #28 OR #27 OR #26 OR #25 OR #24 OR #23 OR #22 OR #21 OR #20 OR #19 OR #18 OR #17 OR #16 OR #15 OR #14 OR #13 OR #12 OR #11 OR #10 OR #9 OR #8 OR #7 OR #6 OR #5 OR #4 Databases=PREVIEWS Timespan=All Years
# 30 TS=(markov or markow or monte carlo) Databases=PREVIEWS Timespan=All Years
# 31 #30 OR #29 Databases=PREVIEWS Timespan=All Years
# 32 #31 AND #3 Databases=PREVIEWS Timespan=All Years