# Appendixes

Appendix A Exact Search Strings

Appendix B Data extraction and related forms

Appendix C Evidence Tables

Appendix D Excluded Studies

Appendix E Additional Acknowledgements