# Acknowledgments

The University of Ottawa Evidence-based Practice Center thanks Dr. David Moher (Director EPC), Dr. Timothy Ramsay (Director Methods Centre, Ottawa Hospital Research Institute) and Ms. Chantelle Marie Garritty (Senior Program Manager, Ottawa Hospital Research Institute) for their intellectual contribution and administrative support. We also give our sincere thanks to Ms. Mary P. Nix and Dr. Gurvaneet Randhawa at the Agency for Healthcare Research and Quality for their tremendous help in thinking though the early phase of topic refinement and analytic framework.