# List of Acronyms/Abbreviations

6-MMP: 6-methylmercaptopurine
6-MMPR: 6-methlyMP ribonucleotide
6-MP: 6-mercaptopurine
6-MTG: 6-methylthioguanine
6-TG: 6-thioguanine
6-tGN: deoxy-6-thioguanosine 5′ triphosphate
6-tIMP: 6-thiomercaptopurine
AACC: American Association for Clinical Chemistry
AHRQ: Agency for Health Research Quality
ALL: acute lymphoblastic leukemia
AO: aldehyde oxidase
AST: aspartate aminotransferase
AZA: azathioprine
CI: confidence interval
CK: creatinine kinase
CLSI: Clinical and Laboratory Standards Institute
CV: coefficient of variance
CLIB: Cochrane Library
FN: false negative
FP: false positive
g: gram
GD: guanine deaminase
h: hour
Hb: haemoglobin
HGPRT: hypoxanthine-guanine phosphoribosyl transferase
HPLC: high performance liquid chromatography
HQOL: health related quality of life
HWE: Hardy-Weinberg equilibrium
IBD: inflammatory bowel disease
IC50: concentration of inhibitor at which enzyme activity is 50 percent of uninhibited activity
ICU: intensive care unit
IMPDH: inosine monophosphate dehydrogenase KQ key question
MALDI-TOF: Matrix-assisted laser desorption/ionization, with time-of-flight mass spectrometry
mg: milligram
n: number in group with particular characteristic
N: total number in study or group
nmol: nanomole
OR: odds ratio
p: probability
PCR: polymerase chain reaction
pmol: picomol
QUADAS: Quality Assessment of Diagnostic Accuracy Studies
RBCs: red blood cells
RFLP: restriction fragment length polymorphism
SAE: serious adverse events
SAM: S-adenosyl-L-methionine
SNPs: single nucleotide polymorphisms
TARGET: TPMT: Azathioprine Response to Genotyping and Enzyme Testing study
TN: true negative
TP: true positive
TPMT: thiopurine methyltransferase
U: unit (nmol/h production in an enzymatic reaction)
WDAE: withdrawal due to adverse events
XO: xanthine oxidase