# References and Included Studies

1 Institute of Medicine Preterm Birth: Causes, Consequences, and Prevention. 2005. Behrman Richard E, Butler Adrienne Stith, editors. The National Academies Press. Washington, D.C.
2 Berman W Jr, Katz R, Yabek SM, Dillon T, Fripp RR, Papile LA. Long-term follow-up of bronchopulmonary dysplasia. J Pediatr. 1986;109(1):45-50. [pmid: 3755166].
3 Heron M, Sutton PD, Xu J, Ventura SJ, Strobino DM, Guyer B. Annual summary of vital statistics: 2007. Pediatrics. 2010;125(1):4-15. [pmid: 20026491].
4 Finer NN, Barrington KJ. Nitric oxide for respiratory failure in infants born at or near term. Cochrane Database Syst Rev. 2006;(4):CD000399. [pmid: 17054129].
5 Palmer RM, Ferrige AG, Moncada S. Nitric oxide release accounts for the biological activity of endothelium-derived relaxing factor. Nature. 1987;327(6122):524-6. [pmid: 3495737].
6 Bin-Nun A, Schreiber MD. Role of iNO in the modulation of pulmonary vascular resistance. J Perinatol. 2008;28(Suppl 3):S84-92. [pmid: 19057617].
7 Kinsella JP, Abman SH. Inhaled nitric oxide: current and future uses in neonates. Semin Perinatol. 2000;24(6):387-95. [pmid: 11153900].
8 Kinsella JP, Ivy DD, Abman SH. Inhaled nitric oxide improves gas exchange and lowers pulmonary vascular resistance in severe experimental hyaline membrane disease. Pediatr Res. 1994;36(3):402-8. [pmid: 7808839].
9 Cornfield DN, Abman SH. Inhalational nitric oxide in pulmonary parenchymal and vascular disease. J Lab Clin Med. 1996;127(6):530-9. [pmid: 8648257].
10 Gianetti J, Bevilacqua S, De Caterina R. Inhaled nitric oxide: more than a selective pulmonary vasodilator. Eur J Clin Invest. 2002;32(8):628-35. [pmid: 12190963].
11 Edwards AD. The pharmacology of inhaled nitric oxide. Arch Dis Child Fetal Neonatal Ed. 1995;72(2):F127-30. [pmid: 7712273].
12 Miller SS, Rhine WD. Inhaled nitric oxide in the treatment of preterm infants. Early Hum Dev. 2008;84(11):703-7. [pmid: 18930359].
13 http://www.accessdata.fda.gov/scripts/cder/drugsatfda/index.cfm?fuseaction=Search.DrugDetails. Last accessed June 14. 2010.
14 Kinsella JP, Abman SH. Clinical approach to inhaled nitric oxide therapy in the newborn with hypoxemia. J. Pediatr. 2000;136(6):717-26. [pmid: 10839866].
15 Kinsella JP, Neish SR, Dunbar Ivy D, Shaffer E, Abman SH. Clinical responses to prolonged treatment of persistent pulmonary hypertension of the newborn with low doses of inhaled nitric oxide. J. Pediatr. 1993;123(1):103-8. [pmid: 8320602].
16 Macrae DJ, Field D, Mercier JC, et al. Inhaled nitric oxide therapy in neonates and children: reaching a European consensus. Intensive Care Med. 2004;30(3):372-80. [pmid: 14722629].
17 Ballard PL, Gonzales LW, Godinez RI, et al. Surfactant composition and function in a primate model of infant chronic lung disease: effects of inhaled nitric oxide. Pediatr Res. 2006;59(1):157-62. [pmid: 16326985].
18 McCurnin DC, Pierce RA, Chang LY, et al. Inhaled NO improves early pulmonary function and modifies lung growth and elastin deposition in a baboon model of neonatal chronic lung disease. Am J Physiol Lung Cell Mol Physiol. 2005;288(3):L450-9. [pmid: 15591412].
19 Cotton RB, Sundell HW, Zeldin DC, et al. Inhaled nitric oxide attenuates hyperoxic lung injury in lambs. Pediatr. Res. 2006;59(1):142-6. [pmid: 16327001].
20 Kinsella JP, Parker TA, Galan H, Sheridan BC, Halbower AC, Abman SH. Effects of inhaled nitric oxide on pulmonary edema and lung neutrophil accumulation in severe experimental hyaline membrane disease. Pediatr Res. 1997;41(4 Pt 1):457-63. [pmid: 9098845].
21 Tang JR, Markham NE, Lin YJ, et al. Inhaled nitric oxide attenuates pulmonary hypertension and improves lung growth in infant rats after neonatal treatment with a VEGF receptor inhibitor. Am J Physiol Lung Cell Mol Physiol. 2004;287(2):L344-51. [pmid: 15064225].
22 Lin YJ, Markham NE, Balasubramaniam V, et al. Inhaled nitric oxide enhances distal lung growth after exposure to hyperoxia in neonatal rats. Pediatr Res. 2005;58(1):22-9. [pmid: 15879297].
23 Weinberger B, Laskin DL, Heck DE, Laskin JD. The toxicology of inhaled nitric oxide. Toxicol Sci. 2001;59(1):5-16. [pmid: 11134540].
24 Frank L, Groseclose EE. Preparation for birth into an O2-rich environment: the antioxidant enzymes in the developing rabbit lung. Pediatr Res. 1984;18(3):240-4. [pmid: 6728556].
25 Gaston B, Drazen JM, Loscalzo J, Stamler JS. The biology of nitrogen oxides in the airways. Am J Respir Crit Care Med. 1994;149(2 Pt 1):538-51. [pmid: 7508323].
26 Centers for Disease Control. Recommendations for occupational safety and health standards. Morbid Mortal Wkly. 1988;report 37(supplement 7, 21).
27 Gries A, Herr A, Motsch J, et al. Randomized, placebo-controlled, blinded and cross-matched study on the antiplatelet effect of inhaled nitric oxide in healthy volunteers. Thromb Haemost. 2000;83(2):309-15. [pmid: 10739391].
28 Albert J, Norman M, Wallen NH, Frostell C, Hjemdahl P. Inhaled nitric oxide does not influence bleeding time or platelet function in healthy volunteers. Eur J Clin Invest. 1999;29(11):953-9. [pmid: 10583440].
29 Roberts JD, Polaner DM, Lang P, Zapol WM. Inhaled nitric oxide in persistent pulmonary hypertension of the newborn. Lancet. 1992;340(8823):818-9. [pmid: 1357245].
30 Hintz SR, Van Meurs KP, Perritt R, et al. Neurodevelopmental outcomes of premature infants with severe respiratory failure enrolled in a randomized controlled trial of inhaled nitric oxide. J Pediatr. 2007;151(1):16-22. 22.e1. 3. [pmid: 17586184].
31 Barrington Keith J, Finer Neil. Inhaled nitric oxide for respiratory failure in preterm infants. Barrington Keith J, Finer Neil, editors. Inhaled Nitric Oxide for Respiratory Failure in Preterm Infants. Cochrane Database of Systematic Reviews: Reviews 2007 Issue 3. John Wiley & Sons, Ltd. Chichester, UK. [doi: 10.1002/14651858.CD000509.Pub3]. 2007;(3).
32 Hoehn T, Krause MF, Buhrer C. Meta-analysis of inhaled nitric oxide in premature infants: An update. Klin. Padiatr. 2006;218(2):57-61. [pmid: 16506103].
33 Steinhorn RH, Porta NF. Use of inhaled nitric oxide in the preterm infant. Curr Opin Pediatr. 2007;19(2):137-41. [pmid: 17496754].
34 Ballard RA, Truog WE, Cnaan A, et al. Inhaled nitric oxide in preterm infants undergoing mechanical ventilation. New Engl. J. Med. 2006;355(4):343-53. [pmid: 16870913].
35 Huddy CL, Bennett CC, Hardy P, et al. The INNOVO multicentre randomised controlled trial: neonatal ventilation with inhaled nitric oxide versus ventilatory support without nitric oxide for severe respiratory failure in preterm infants: follow up at 4-5 years. Arch Dis Child Fetal Neonatal Ed. 2008;93(6):F430-5. [pmid: 18375612].
36 Watson RS, Clermont G, Kinsella JP, et al. Clinical and economic effects of iNO in premature newborns with respiratory failure at 1 year. Pediatrics. 2009;124(5):1333-43. [pmid: 19841128].
37 Kinsella JP, Cutter GR, Walsh WF, et al. Early inhaled nitric oxide therapy in premature newborns with respiratory failure. N Engl J Med. 2006;355(4):354-64. [pmid: 16870914].
38 Tanaka Y, Hayashi T, Kitajima H, Sumi K, Fujimura M. Inhaled nitric oxide therapy decreases the risk of cerebral palsy in preterm infants with persistent pulmonary hypertension of the newborn. Pediatrics. 2007;119(6):1159-64. [pmid: 17545384].
39 Van Meurs KP, Hintz SR, Ehrenkranz RA, et al. Inhaled nitric oxide in infants >1500 g and <34 weeks gestation with severe respiratory failure. J Perinatol. 2007;27(6):347-52. [pmid: 17443204].
40 Van Meurs KP, Wright LL, Ehrenkranz RA, et al. Inhaled nitric oxide for premature infants with severe respiratory failure. N Engl J Med. 2005;353(1):13-22. [pmid: 16000352].
41 Ambalavanan N, Van Meurs KP, Perritt R, et al. Predictors of death or bronchopulmonary dysplasia in preterm infants with respiratory failure. J Perinatol. 2008;28(6):420-6. [pmid: 18337740].
42 Bruckner TA, Carlo WA, Ambalavanan N, Gould JB. Neonatal mortality among low birth weight infants during the initial months of the academic year. J Perinatol. 2008;28(10):691-5. [pmid: 18596712].
43 Hoo A-F, Beardsmore CS, Castle RA, et al. Respiratory function during infancy in survivors of the INNOVO trial. Pediatr. Pulmonol. 2009;44(2):155-61. [pmid: 19148936].
44 Hibbs AM, Walsh MC, Martin RJ, et al. One-year respiratory outcomes of preterm infants enrolled in the Nitric Oxide (to prevent) Chronic Lung Disease trial. J Pediatr. 2008;153(4):525-9. [pmid: 18534620].
45 Kinsella JP, Cutter WF, Gerstman DR, et al. Outcomes of Premature Infants Enrolled in the Early Inhaled Nitric Oxide for the Prevention of Chronic Lung Disease Trial. PASA Abstract, E-PAS2009:2155.6. 2009.
46 Keller RL, Walsh E, Vittinghoff E, et al. Response to inhaled nitric oxide (iNO) and neurodevelopmental impairment (NDI) in NO CLD. PASA Abstract, E-PAS2009:2155.7. 2009.
47 Clark RH, Ursprung RL, Walker MW, Ellsbury DL, Spitzer AR. The changing pattern of inhaled nitric oxide use in the neonatal intensive care unit. J Perinatol. 2010.
48 Berlin JA. Does blinding of readers affect the results of meta-analyses? University of Pennsylvania Meta-analysis Blinding Study Group. Lancet. 1997;350(9072):185-6. [pmid: 9250191].
49 The Cochrane Collaboration. Cochrane Handbook for Systematic Reviews of Interventions Version 5.0.2. updated September 2009. Higgins JPT, Green S, editors. The Cochrane Collaboration. 2009.
50 Wells GA, Shea B, O'Connell D, Peterson J, Welch V, Losos M, Tugwell P. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomized studies in meta-analyses. Department of Epidemiology and Community Medicine. University of Ottawa, Canada. http://www.lri.ca/programs/ceu/oxford.htm.
51 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. BMJ. 2004;328(7454):1490. [pmid: 15205295].
52 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. 2010;63(5):513-23. [pmid: 19595577].
53 Wallace BC, Schmid CH, Lau J, Trikalinos TA. Meta-Analyst: software for meta-analysis of binary, continuous and diagnostic data. BMC Med Res Methodol. 2009;9(80).
54 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
55 Schlesselman J, Stolley P. Case-control studies, Design, conduct, analysis. New York. Oxford University Press. 1982.
56 Mestan KK, Marks JD, Hecox K, Huo D, Schreiber MD. Neurodevelopmental outcomes of premature infants treated with inhaled nitric oxide. N Engl J Med. 2005;353(1):23-32. [pmid: 16000353].
57 Walsh MC, Hibbs AM, Martin CR, et al. Two year neurodevelopmental outcomes of ventilated preterm infants treated with inhaled nitric oxide. J Pediatr. 2010;156(4):556-61.e1. [pmid: 20138299].
58 Schreiber MD, Gin-Mestan K, Marks JD, Huo D, Lee G, Srisuparp P. Inhaled Nitric Oxide in Premature Infants with the Respiratory Distress Syndrome. New Engl. J. Med. 2003;349(22):2099-107. [pmid: 14645637].
59 Kinsella JP, Walsh WF, Bose CL, et al. Inhaled nitric oxide in premature neonates with severe hypoxaemic respiratory failure: A randomised controlled trial. Lancet. 1999;354(9184):1061-5. [pmid: 10509496].
60 Franco-Belgium Collaborative NO Trial Group. Early compared with delayed inhaled nitric oxide in moderately hypoxaemic neonates with respiratory failure: a randomised controlled trial. The Franco-Belgium Collaborative NO Trial Group. Lancet. 1999;354(9184):1066-71. [pmid: 10509497].
61 Hascoet JM, Fresson J, Claris O, et al. The safety and efficacy of nitric oxide therapy in premature infants. J. Pediatr. 2005;146(3):318-23. [pmid: 15756211].
62 Mercier JC, Hummler H, Durrmeyer X, et al. Inhaled nitric oxide for prevention of bronchopulmonary dysplasia in premature babies (EUNO): a randomised controlled trial. Lancet. 2010;376(9738):346-54. [pmid: 20655106].
63 Field D, Elbourne D, Truesdale A, et al. Neonatal Ventilation With Inhaled Nitric Oxide Versus Ventilatory Support Without Inhaled Nitric Oxide for Preterm Infants With Severe Respiratory Failure: the INNOVO multicentre randomised controlled trial (ISRCTN 17821339). Pediatrics. 2005;115(4):926-36. [pmid: 15805366].
64 Subhedar NV, Ryan SW, Shaw NJ. Open randomised controlled trial of inhaled nitric oxide and early dexamethasone in high risk preterm infants. Arch Dis Child Fetal Neonatal Ed. 1997;77(3):F185-90. [pmid: 9462187].
65 Su PH, Chen JY. Inhaled nitric oxide in the management of preterm infants with severe respiratory failure. J Perinatol. 2008;28(2):112-6. [pmid: 17989696].
66 Srisuparp P, Heitschmidt M, Schreiber MD. Inhaled nitric oxide therapy in premature infants with mild to moderate respiratory distress syndrome. J Med Assoc Thai. 2002;85(Suppl 2):S469-78. [pmid: 12403222].
67 Dani C, Bertini G, Pezzati M, Filippi L, Cecchi A, Rubaltelli FF. Inhaled nitric oxide in very preterm infants with severe respiratory distress syndrome. Acta Paediatr. 2006;95(9):1116-23. [pmid: 16938760].
68 Kumar VH, Hutchison AA, Lakshminrusimha S, Morin FC 3rd, Wynn RJ, Ryan RM. Characteristics of pulmonary hypertension in preterm neonates. J Perinatol. 2007;27(4):214-9. [pmid: 17330053].
69 Uga N, Ishii T, Kawase Y, Arai H, Tada H. Nitric oxide inhalation therapy in very low-birthweight infants with hypoplastic lung due to oligohydramnios. Pediatr. Int. 2004;46(1):10-4. [pmid: 15043657].
70 Banks BA, Seri I, Ischiropoulos H, Merrill J, Rychik J, Ballard RA. Changes in oxygenation with inhaled nitric oxide in severe bronchopulmonary dysplasia. Pediatrics. 1999;103(3):610-8. [pmid: 10049965].
71 Clark PL, Ekekezie II, Kaftan HA, Castor CA, Truog WE. Safety and efficacy of nitric oxide in chronic lung disease. Arch Dis Child Fetal Neonatal Ed. 2002;86(1):F41-5. [pmid: 11815547].
72 Cheung P-Y, Peliowski A, Robertson CMT. The outcome of very low birth weight neonates ((less-than or equal to)1500 g) rescued by inhaled nitric oxide: Neurodevelopment in early childhood. J. Pediatr. 1998;133(6):735-9. [pmid: 9842035].
73 Yadav M, Emmerson AJ. Inhaled nitric oxide in premature neonates. Lancet. 1999;354(9196):2162-3. [pmid: 10609839].
74 Dewhurst C, Ibrahim H, Gothberg S, Jonsson B, Subhedar N. Use of inhaled nitric oxide in the new born period: Results from the European inhaled nitric oxide registry. Acta Paediatr. 2010;99(6):854-60. [pmid: 20219040].
75 Ballard RA. Inhaled nitric oxide in preterm infants--correction. N Engl J Med. 2007;357(14):1444-5. [pmid: 17914048].
76 Bennett AJ, Shaw NJ, Gregg JE, Subhedar NV. Neurodevelopmental outcome in high-risk preterm infants treated with inhaled nitric oxide. Acta Paediatr. 2001;90(5):573-6. [pmid: 11430720].
77 Chock VY, Van Meurs KP, Hintz SR, et al. Inhaled nitric oxide for preterm premature rupture of membranes, oligohydramnios, and pulmonary hypoplasia. Am J Perinatol. 2009;26(4):317-22. [pmid: 19067285].
78 Hamon I, Fresson J, Nicolas MB, Buchweiller MC, Franck P, Hascoet JM. Early inhaled nitric oxide improves oxidative balance in very preterm infants. Pediatr Res. 2005;57(5 Pt 1):637-43. [pmid: 15746261].
79 McAdams RM, Garza-Cox S, Yoder BA. Early-onset neonatal pneumococcal sepsis syndrome. Pediatr Crit Care Med. 2005;6(5):595-7. [pmid: 16148824].
80 Ballard RA. Inhaled nitric oxide in preterm infants--correction. N Engl J Med. 2007;357(14):1444-5. [pmid: 17914048].
81 Ryan SW, Nycyk J, Shaw BN. Prediction of chronic neonatal lung disease on day 4 of life. Eur J Pediatr. 1996;155(8):668-71. [pmid: 8839722].
82 Northway WH Jr, Rosan RC, Porter DY. Pulmonary disease following respirator therapy of hyaline-membrane disease: bronchopulmonary dysplasia. N Engl J Med. 1967;276:357-68. [pmid: 5334613].
83 Van Marter LJ. Epidemiology of bronchopulmonary dysplasia. Semin Fetal Neonatal Med. 2009;14(6):358-66. [pmid: 19783238].
84 Walsh MC, Wilson-Costello D, Zadell A, Newman N, Fanaroff A. Safety, reliability, and validity of a physiologic definition of bronchopulmonary dysplasia. J Perinatol. 2003;23:451-6. [pmid: 13679930].
85 Tennakoon J, Koh TH, Alcock G. Pyloric stenosis in a newborn baby with polycystic kidneys. J Perinatol. 2007;27(2):125-6. [pmid: 17262047].
86 Institute of Medicine, Committee on Understanding Premature Birth and Assuring Healthy Outcomes, Board on Health Sciences Policy, Preterm Birth: Causes, Consequences and Prevention. Behrman RE, Stith Butler A, editors. Washington, DC. National Academies Press. 2007.
87 Papile LA, Burnstein J, Burnstein R, Koffler H. Incidence and evolution of subependymal and intraventricular hemorrhage: a study of infants less than 1500 gm. J Pediatr. 1978;92:529-34. [pmid: 305471].
88 Palisano R, Rosenbaum P, Walter S, Russell D, Wood E, Galuppi B. Development and reliability of a system to classify gross motor function in children with cerebral palsy. Dev Med Child Neurol. 1997;39(4):214-23. [pmid: 9183258].
89 Elliot CD, Smith P, McCulloch K. British ability scales second edition (BAS II). Windsor. NFER-Nelson. 1996.
90 Kuczmarski RJ, Ogden CL, Grummer-Strawn LM, et al. CDC growth charts: United States Advance data from vital and health statistics. Hyattsville, MD. National Center for Health Statistics. 2000;(314).
91 Da Costa DE, Nair AK, Pai MG, Al Khusaiby SM. Steroids in full term infants with respiratory failure and pulmonary hypertension due to meconium aspiration syndrome. Eur. J. Pediatr. 2001;160(3):150-3. [pmid: 11277374].
92 Groenendaal F, Lammers H, Smit D, Nikkels PG. Nitrotyrosine in brain tissue of neonates after perinatal asphyxia. Arch Dis Child Fetal Neonatal Ed. 2006;91(6):F429-33. [pmid: 16835259].
93 Skimming JW, DeMarco VG, Cassin S. The effects of nitric oxide inhalation on the pulmonary circulation of preterm lambs. Pediatr Res. 1995;37(1):35-40. [pmid: 7700732].
94 Cools F, Henderson-Smart DJ, Offringa M, Askie LM. Elective high frequency oscillatory ventilation versus conventional ventilation for acute pulmonary dysfunction in preterm infants. Cochrane Database Syst Rev. Jul 8. 2009;(3):CD000104. [pmid: 19588317].
95 Askie L, Ballard R, Cutter G, et al. Inhaled Nitric Oxide in Preterm Infants: An Individual Patient Data Meta-Analysis. PASA Abstract, E-PAS2010:1172.7. 2010.
96 Askie LM, Ballard RA, Cutter G, et al. Inhaled Nitric Oxide in preterm infants: a systematic review and individual patient data meta-analysis. BMC Pediatr. 2010;10:15. [pmid: 20331899].