# Executive Summary

## Background

Neonatal lung disease is the most common complication of preterm delivery and causes significant morbidity and mortality. Disorders of prematurity and respiratory distress are among the leading causes of infant mortality in the U.S.

The use of inhaled nitric oxide (iNO) has been approved by the U.S. Food and Drug Administration for respiratory failure of the term and near-term infant and is recommended by professional societies, such as the American Academy of Pediatrics. Evidence supporting the use of iNO in term or near term infants is summarized by a Cochrane review that found that use of iNO therapy reduced the need for extracorporeal membrane oxygenation in term and near term (> 34 weeks gestation) infants with respiratory failure, but did not change neurodevelopmental outcomes at two to three years of age. There is a need to consider the evidence about the use of iNO therapy in preterm infants ≤ 34 weeks of gestation.

This report summarizes the available evidence on the use of iNO in preterm infants born at or before 34 weeks gestation age who receive respiratory support. The report addresses the following questions:

1. Does iNO therapy increase survival and/or reduce the occurrence or severity of bronchopulmonary dysplasia (BPD) among premature infants who receive respiratory support?
2. Are there short-term risks of iNO therapy among premature infants who receive respiratory support?
3. Are there effects of iNO therapy on long-term pulmonary and/or neurodevelopmental outcomes among premature infants who receive respiratory support?
4. Does the effect of iNO therapy on BPD and/or death or neurodevelopmental impairment vary across subpopulations of premature infants?
5. Does the effect of iNO therapy on BPD and/or death or neurodevelopmental impairment vary by timing of initiation, mode of delivery, dose and duration, or concurrent therapies?

## Methods

We searched MEDLINE, EMBASE, the Cochrane Central Register of Controlled Studies (CENTRAL) and PsycInfo in June 2010. We also searched the proceedings of the 2009 and 2010 Pediatric Academic Societies Meeting and ClinicalTrials.gov. We identified additional studies from reference lists of eligible articles and relevant reviews, as well as from technical experts. Questions were developed in collaboration with technical experts, including the chair of the upcoming National Institutes of Health Office of Medical Applications of Research Consensus Development Conference. We limited our review to randomized controlled trials (RCTs) for the question of survival or occurrence of bronchopulmonary dysplasia (BPD) and for the question on short-term risks. All study designs were considered for long-term pulmonary or neurodevelopmental outcomes, and for questions about whether outcomes varied by subpopulation or by intervention characteristics. Two investigators independently screened search results, and abstracted data from eligible articles.

## Results

We identified a total of 14 RCTs, reported in 23 articles, and eight cohort studies addressing our questions. Our major findings are summarized by key question.

### Key Question 1 Does iNO therapy increase survival and/or reduce the occurrence or severity of bronchopulmonary dysplasia (BPD) among premature infants who receive respiratory support?

- There is no statistically significant effect of iNO compared to placebo on survival or mortality rates in preterm NICU infants requiring mechanical ventilation.
- There is insufficient evidence to determine whether iNO reduces the rate of bronchopulmonary dysplasia (BPD), as defined by requiring supplemental oxygen at 36 weeks postmenstrual age, in preterm NICU infants requiring mechanical ventilation.
- There is small but statistically significant reduction in the composite variable of death or BPD at 36 weeks PMA for infants treatment with iNO compared to infants in control groups.
- Preterm infants who required mechanical ventilation and were the subjects of randomized controlled trials of inhaled nitric oxide were a high risk population with high mortality and BPD rates during NICU hospitalization.

Fourteen RCTs addressed death or BPD. The definition of outcomes, specifically the time outcomes were assessed, differed across studies. Evidence on the outcome of death was considered of moderate strength as was BPD at 36 weeks PMA.

### Key Question 2 Are there short-term risks of iNO therapy among premature infants who receive respiratory support?

- There is insufficient evidence of a neuroprotective effect of iNO in preterm infants.
- There is no evidence that treatment of preterm infants with iNO influences the rates of other complications of prematurity, including patent ductus arteriosus (PDA), sepsis, necrotizing enterocolitis (NEC), severe retinopathy of prematurity (ROP), pulmonary hemorrhage, or air leaks.
- No study reported accumulation of toxic levels of methemoglobin or nitrogen dioxide.

Fourteen RCTs provided data on short term risks of iNO therapy. There was moderate strength of evidence on IVH, PVL, PVL, PDA and NEC.

### Key Question 3 Are there effects of iNO therapy on long-term pulmonary and/or neurodevelopmental outcomes among premature infants who receive respiratory support?

- There is insufficient evidence to determine whether iNO therapy in preterm infants who require respiratory support influences the incidence of cognitive, motor or sensory impairments, or neurodevelopmental disability.
- There is evidence suggesting that iNO therapy in preterm infants who require respiratory support may decrease the need for respiratory medications at one year of age.
- There is insufficient evidence to determine whether iNO therapy in preterm infants who require respiratory support impacts long-term health outcomes such as respiratory symptoms, rehospitalization after NICU discharge, and growth.

Twelve articles reported long term outcomes; nine RCTs and three observational studies. Evidence was considered to be of low strength for neurodevelopmental and coginitive outcomes and for cerebral palsy. Evidence for death as a long term outcome was moderate. Evidence on all of the other long term outcomes was considered low or insufficient.

### Key Question 4 Does the effect of iNO therapy on BPD and/or death or neurodevelopmental impairment vary across subpopulations of premature infants?

- There is insufficient evidence to determine whether the effect of iNO therapy on mortality, BPD, or motor impairment differs by the birth weight of the treated infants.
- There is insufficient evidence to evaluate the relationship between iNO therapy and infant sex, race/ethnic group, gestational age, or socioeconomic status.
- There are no published data available to evaluate the association between iNO therapy and, antenatal steroids, chorioamnionitis, multiple birth, or growth restriction.
- There is insufficient evidence concerning the relationship between iNO therapy and the severity of illness.
- There is insufficient evidence that iNO therapy improves outcome of infants suffering respiratory failure from pulmonary hypoplasia, respiratory distress syndrome or pulmonary hypertension.
- There is no consistent pattern of infants that respond to iNO therapy and those that do not.
- There is no consistent pattern of infants that respond to iNO therapy and those that do not.

We identified six RCTs with five followup studies, and six other studies, that addressed this question. The definition of outcomes varied across studies, and many of the subgroup analyses were by post hoc analyses. Death, BPD at 36 weeks PMA and survival without BPD had moderate strength of evidence. All other outcomes for this question had evidence judged to be low strength.

### Key Question 5 Does the effect of iNO therapy on BPD and/or death or neurodevelopmental impairment vary by timing of initiation, mode of delivery, dose and duration, or concurrent therapies?

- There is insufficient evidence to determine if initiating iNO therapy for acute respiratory distress at ≤ 3 days reduces the risk of death or bronchopulmonary dysplasia (BPD) at 36 weeks PMA, or death and neurodevelopmental disability at 1 year of age, corrected for gestational age at birth.
- In infants with developing BPD, there is insufficient evidence to determine if treatment with iNO during the second week after birth improves survival without BPD compared with treatment during the third week after birth.
- There is insufficient evidence to determine the effect of delivery of iNO by high frequency ventilation on either death or BPD, or neurodevelopmental outcome compared with conventional ventilation.
- There is insufficient evidence to support an optimal dose of iNO or duration of exposure to improve outcome or prevent harm.
- There is insufficient evidence to determine the effect of iNO with concurrent therapy.

We identified 14 RCTs addressing this question. No studies allowed for assessment of duration of therapy. Comparison across studies was limited by differences in definitions of outcomes. All but two of the studies provided data based on post hoc analysis, and so should be interpreted with caution. Strength of evidence was moderate for survival without BPD and BPD at 36 weeks. For all other outcomes, evidence was low strength.

## Future Research

Current evidence does not support the routine use of iNO to treat premature infants. However, we should not abandon the possibility that iNO may someday become a component of a treatment strategy for some preterm infants receiving respiratory support. Several factors contribute to our recommendation to continue the study of iNO: 1) our finding a small but statistically significant difference in death or BPD at 36 weeks PMA, the common primary outcome variable of 73% of RCT conducted to-date; 2) the statistically significant finding of a diminished need for chronic pulmonary medication at one year corrected age, suggesting less severe lung disease in those treated with iNO, and 3) no studies have been powered to detect meaningful differences in infant functional outcome or quality of life with iNO treatment compared to standard therapy.

Specific considerations for future research are listed below.

## Patients

- RCTs must be adequately powered to assess the effect of iNO on subgroups of preterm infants, such as those of varying birth weight.
- Special care must be taken if infants born at the limit of viability are included in RCTs. These infants do not yet have alveoli (gas exchange occurs through their terminal bronchioles) and their brains do not yet have gyri or sulci. They are most vulnerable to organ injury, which may be most evident on long-term follow-up. Every effort must be taken to obtain pulmonary, neurodevelopmental and health follow-up for all infants in this category.
- There may be a value to viewing the use of iNO in terms of postmenstrual age, which is a better measure of degree of maturation and takes into account both gestational age and chronologic age in developing preterm infants.

## Intervention

- Since the goal is to support pulmonary and brain development in the NICU, courses of iNO given for weeks, not days, should be studied.
- Mode of ventilation should be considered in randomization schemes for trials restricted to infants < 1500 grams, those at highest risk for death, BPD and neurodevelopmental impairment, to adequately address the question concerning mode of delivery.
- As many of the smallest preterm infants are managed with CPAP or high flow nasal cannula alone, without intubation, information concerning iNO delivery with these devices is needed.

## Outcomes

- Future RCTs should require neuroimaging by standardized protocols before trial enrollment, to detect the occurrence and progression of brain injury during iNO treatment.
- Studies should be powered to assess long term neurodevelopmental, pulmonary and other health outcomes.
- Outcomes should focus on functional status and quality of life, as well as neurodevelopmental disabilities.
- Studies are needed to provide information on resource utilization such as rehospitalizations, medications, physicians’ visits. Future focus should be on the real pulmonary problems of prolonged hospitalizations, use of supplemental oxygen and pulmonary medications after NICU discharge, prevalence of reactive airway disease and recurrent hospitalizations.
- Consideration should be given to assess longer term childhood outcomes (e.g., pulmonary function tests, school performances).
- Cost benefit analyses should be conducted with multicenter RCTs of iNO.