# Introduction

## Background

Neonatal lung disease is the most common complication of preterm delivery, and results in significant morbidity and mortality.1 Preterm infants suffer from both acute and chronic respiratory failure as a result of anatomic and biochemical disruption of lung function, lung inflammation and oxidative stress, nutritional deficiencies, and arrest of tracheobronchial and pulmonary vascular growth (see Appendix A, List of Acronyms). Treatment for acute respiratory failure often contributes to evolving bronchopulmonary dysplasia (BPD) and chronic respiratory failure, due to barotrauma and oxygen toxicity from prolonged respiratory support, deficient nutrition, as well as immaturity of lung growth, vascular development and immunologic defenses. Pulmonary hypertension may occur in association with acute and/or chronic respiratory failure.2 Multiple etiologies make finding an effective treatment for respiratory failure in preterm infants challenging. Disorders related to prematurity and respiratory distress are among the leading causes of infant mortality in the U.S.3

### Treatment Options

Treatment options for respiratory failure in preterm infants include a variety of modalities. Prenatal steroids, antibiotics, exogenous surfactant replacement, tidal volume ventilation, conventional ventilation, continuous positive airway pressure, high flow oxygen administration, and high frequency ventilation are all used as therapeutic modalities. Treatment of preterm infants with inhaled nitric oxide (iNO) as a rescue therapy for refractory hypoxemic respiratory failure is an extension of the relative success of the treatment of term and near term infants with iNO.4

### Mechanism of Action

Endogenous nitric oxide (NO), produced in vascular endothelial cells, regulates vascular tone.5 NO diffuses into adjacent vascular smooth muscle cells and activates soluble guanylyl cyclase, leading to the activation of cGMP-dependent protein kinase.6 The subsequent signal transduction cascade results in vascular smooth muscle cell relaxation and vasodilatation.6, 7 When exogenous nitric oxide is inhaled, it is a selective pulmonary vasodilator decreasing pulmonary vascular resistance without affecting systemic vascular tone.8 This occurs because the low molecular weight and high lipid solubility of inhaled NO allows rapid diffusion in the ventilated lung from the alveoli to direct contact with arterioles.9 In addition, NO has a very short half-life,5, 10 and NO is rapidly deactivated by heme in hemoglobin reducing its effect on other smooth muscle in the body.11, 12

Since 1999, iNO has been approved by the U.S. Food and Drug Administration (FDA) for the treatment of severe hypoxemia and persistent pulmonary hypertension of the newborn (PPHN) in term and near term infants.13 PPHN is a syndrome associated with several neonatal cardio pulmonary etiologies, and is characterized by high pulmonary vascular resistance (PVR).7 High PVR causes extrapulmonary shunting of blood right to left across the ductus arteriosus and/or foramen ovale and may cause critical hypoxemia.7, 14 In newborns, the use of iNO therapy to selectively lower PVR and reduce extrapulmonary shunting accounts for the acute improvement in oxygenation observed with PPHN.15

In severe respiratory failure, hypoxemia may also occur with intrapulmonary shunting, due to atelectasis and ventilation/perfusion inequality.7 Thus, inhaled nitric oxide may also benefit preterm infants with parenchymal lung disease by redistributing pulmonary blood flow, thereby reducing intrapulmonary shunting and ventilation: perfusion mismatching.16 Both mechanisms reduce secondary lung injury from barotrauma, volutrauma, and oxygen toxicity by reducing the need for prolonged respiratory support.

Inhaled NO may have other characteristics beneficial to preterm infants. Ballard, 2006 demonstrated that iNO therapy in a preterm baboon model of evolving BPD increased maximal lung volume, decreased the total protein:phospholipid (PL) ratio of surfactant, and had little effect on the composition of surfactant PL or proteins, suggesting that iNO may be associated with less severe lung injury and improved surfactant function.17 In a companion study, again in a premature baboon model, McCurnin, 2005 reported lung growth after iNO therapy mimicked that seen in utero.18 Inhaled NO has also been shown to reduce inflammation and oxidant injury in animal models of hyperoxic lung injury.19, 20 Furthermore, NO may play a role in early lung development. A newborn rat model with both structural and functional characteristics of BPD21 showed a reduction in pulmonary hypertension and a preservation of lung growth with early introduction of iNO therapy.21 Similarly, following exposure to hyperoxia in neonatal rats, Lin, 2005 found that iNO exposure during recovery restored distal lung growth and alveolarization.22

Inhaled NO has several potential toxic complications from both direct and indirect effects.23 The preterm infant is particularly vulnerable to reactive oxidant species induced damage due to the relative inadequacy of antioxidant enzymes in the lung.24 In the presence of oxygen, nitric oxide forms nitrogen dioxide (NO_2_), a potent inflammatory agent leading to pulmonary edema and lung injury, but the formation is slow at low levels of NO_2_.11, 25 A NO_2_dose of 5 ppm is considered the maximum environmentally safe dose, necessitating careful monitoring of infants receiving iNO therapy.26 In simulation, delivery of 20 ppm iNO at high oxygen concentrations resulted in the formation of < 1 ppm NO_2_. NO may also adversely affect platelet aggregation and adhesion,27 although the evidence is conflicting28 and has not been reported in trials with infants.

Methemoglobinemia, the resultant reaction of nitric oxide with hemoglobin, reduces oxygen carrying capacity at high concentrations. Accumulation of toxic levels of methemogolobin have not been demonstrated when iNO is delivered at < 80ppm,29 the range in which most infants are treated, but requires constant monitoring during treatment.

### FDA Approved Indication and Usage

The U.S. FDA approved iNO for use in intubated full term and late preterm infants with hypoxemic respiratory failure in 1999^13^ Current labeling of iNO is for use in respiratory failure in term and near term infants (> 34 weeks gestation). The initial recommended starting dose for these infants is 20 ppm with continued use for 14 days or until improvement in the underlying disease process results in normal oxygen saturations. The dose is weaned incrementally with improving oxygen saturations beginning as soon as four hours after the initiation of therapy, to 5 ppm before discontinuation. For infants that do not respond to initial iNO therapy, the dose may be increased to 40 to 80 ppm. Brief exposure to these higher doses appears to be safe, but sustained treatment with 80 ppm will increase the risk of methemoglobinemia,7 with little added clinical benefit.

### Utilization of iNO

Since the FDA approval for use of iNO in full term and late preterm infants, a number of studies have been conducted on the use of iNO in clinically diverse populations of preterm infants.30-40 These studies demonstrate significant variability in their clinical indications for the use of iNO, from its prophylactic use in preterm infants with mild acute respiratory distress to prevent BPD and chronic lung disease, to its use as a late rescue therapy for preterm infants with severe BPD, with resulting wide variations in inclusion and exclusion criteria for study samples. There has been considerable variation in dosage and timing of iNO among studies. Differing findings regarding pulmonary effects and effects on the most common primary outcome variable, death or BPD, raises concerns about gaps in our understanding of physiological effects of iNO in the rapidly developing preterm lung. In addition, differences in the direction of effect on the developing preterm brain raise questions as to whether treatment of preterm infants with iNO increases or decreases the incidence of brain injury.

This controversy has resulted in wide variations in clinical practice, as reports of the longer term pulmonary and neurodevelopmental outcomes at ages two to six years are just emerging.

## Purpose of This Evidence Report

Inhaled NO has demonstrated efficacy in improving oxygenation and reducing the need for extracorporeal membrane oxygenation (ECMO) in late preterm infants born after 34 weeks gestation and full term infants with respiratory failure, with no evidence of long term benefits.4 Despite the approved use of iNO in full term and late preterm infants, the developmentally distinct mechanisms of respiratory failure and differing cardiovascular, pulmonary, and pharmacokinetic characteristics of more immature infants require systematic study of the short and long term outcomes for preterm infants treated with iNO to prevent or treat respiratory failure.

A 2006 meta-analysis included five randomized controlled trials (RCTs) with 808 infants born before 34 weeks gestation.32 The authors concluded that while preterm infants treated with iNO had reduced treatment failure (death or chronic lung disease (CLD); RR 0.81 (0.70, 0.93)) further research was needed on risks and on later neurodevelopmental outcomes. A 2007 Cochrane review of 11 RCTs analyzed data on 3,251 preterm infants (defined as < 35 weeks gestation) in terms of illness severity, dose and timing of iNO.31 The Cochrane review concluded that iNO has no proven efficacy as a rescue therapy to treat very ill ventilated preterm infants, and it may increase the incidence of brain injury (one trial was stopped early).31 It did not appear to prevent chronic lung disease or BPD in preterm infants. Subgroup analyses in some of the multicenter RCTs of iNO in preterm infants suggest that iNO may be beneficial in some preterm infants (e.g., those with higher birth weights, milder respiratory illness, or persistent pulmonary hypertension).32, 40-42

The Cochrane review acknowledged very limited data on long term outcomes of preterm infants treated with iNO. If iNO is beneficial, the number need to treat would be very large. Papers published or presented from 2007 to present report conflicting results as to whether, in preterm infants, iNO has beneficial, adverse, or no effects on long term neurodevelopmental and pulmonary outcomes.30, 43-46

Despite the ongoing controversy, iNO continues to be used for hypoxemic respiratory failure in preterm infants < 34 weeks gestation even with potential harm to the developing lungs and brain.47 There is an urgent need to weigh the current evidence as to whether iNO is a safe and effective treatment in preterm infants.

The Office of Medical Applications of Research (OMAR) at the National Institutes of Health (NIH) scheduled an NIH Consensus Development Conference: Inhaled Nitric Oxide in Preterm Infants to be held in October 2010. The Evidence-based Practice Center at the Johns Hopkins University (JHU) was asked by OMAR and the Agency for Healthcare Research and Quality (AHRQ) to prepare an evidence report for this conference.

## Key Questions

We sought to identify and synthesize evidence addressing the following questions:

1. Does inhaled nitric oxide (iNO) therapy increase survival and/or reduce the occurrence or severity of bronchopulmonary dysplasia (BPD) among premature infants who receive respiratory support?
2. Are there short term risks of iNO therapy among premature infants who receive respiratory support?
3. Are there effects of iNO therapy on long term pulmonary and/or neurodevelopmental outcomes among premature infants who receive respiratory support?
4. Does the effect of iNO therapy on BPD and/or death or neurodevelopmental impairment vary across subpopulations of premature infants?
5. Does the effect of iNO therapy on BPD and/or death or neurodevelopmental impairment vary by timing of initiation, mode of delivery, dose and duration, or concurrent therapies?

For the purposes of our review, we sought studies that included infants less than or equal to 34 weeks gestation age. The outcomes of interest are described in detail in Chapter 2.