# Appendixes

Appendix A List of Acronyms

Appendix B Detailed Electronic Database Search Strategies

Appendix C Screen and Data Abstraction Forms

Appendix D List of Excluded Articles

Appendix E Evidence Tables