# Evidence Tables

Evidence Table 1 Risk of bias in randomized controlled trials

Author, year | Followup studies | sequence adequately generated | allocation adequately concealed | allocated intervention adequately prevented for personnel during the study(ST) | allocated intervention adequately prevented for outcome assessors during the study (LT) | allocated intervention adequately prevented for personnel during the study(LT) | allocated intervention adequately prevented for outcome assessors during the study (LT) | incomplete outcome data adequately addressed (ST) | incomplete outcome data adequately addressed (LT) | reports of the study free of suggestion of selective outcome reporting | free of other problems that could put it at a high risk of bias | RoB Score
Ballard, 2006^1^ | HIbbs, 2007^2^ Walsh, 2010^3^ | + | + | + | + | + | + | + | + | + | + | good
Dani, 2006^4^ | | 0 | + | - | - | | | | | + | - | poor
Fanco-Belgium, 1999^5^ | | | + | | + | - | - + | 0 | 0 | + | + | fair
Field, 2005^6^ | Huddy, 2008^7^ | - | + | - | - | - | - | - | - | - | - | poor
Hascoet, 2005^8^ | Hamon, 2005^9^ | + | + | 0 | 0 | 0 | 0 | + | + | 0 | + | fair
Kinsella, 1999^10^ | | + | + | + | + | + | + | + | + | + | + | good
KinsellaM, 2006^11^ | Watson, 2009^12^ | + | + | + | + | | | + | | + | + | good
Mercier, 2010{#122 62} | | + | + | + | + | + | + | + | 0 | | + | fair
Schreiber, 2003^13^ | Mestan, 2005^14^ | + | + | + | + | | | + | | + | + | good
Srisuparp, 2002^15^ | | + | 0 | 0 | 0 | 0 | 0 | - | + | - | - | poor
Su, 2008^16^ | | + | 0 | - | 0 | - | 0 | - | 0 | + | 0 | poor
Subhedar, 1997^17^ | Bennett, 2001^18^ | + | 0 | - | - | 0 | 0 | + | 0 | 0 | - | poor
Van Meurs, 2005^19^ | Chock, 2009^20^ Hintz, 2007^21^ | + | + | + | + | | | + | | + | + | good
Van Meurs, 2007^22^ | Chock20 | + | + | + | + | + | + | + | + | + | + | good

KEY
Category | Question | Yes | No | Unclear
Sequence generation: | Was the allocation sequence adequately generated? | + | - | 0
Allocation concealment: | Was the allocation adequately concealed | + | - | 0
Blinding of personnel (short-term outcomes) | Was knowledge of the allocation intervention adequately prevented for personnel during the study? | + | - | 0
Blinding of outcome assessors (short-term outcomes) | Was knowledge of the allocated intervention adequately preventes for outcome assessors during the study? | + | - | 0
Blinding of personnel long-term outcomes) | Was knowledge of the allocation intervention adequately prevented for personnel during the study? | + | - | 0
Blinding of outcome assessors Long-term outcomes) | Was knowledge of the allocated intervention adequately preventes for outcome assessors during the study? | + | - | 0
Incomplete outcome data (short-term) | Were incomplete data adequately addressed? | + | - | 0
Incomplete outcome data (short-term) | Were incomplete data adequately addressed? | + | - | 0
Selective outcome reporting | Are reports of the study free of suggestion of selective outcome reporting? | + | - | 0
Other sources of bias | Was the study apparently free of other problems that could put it at high risk of bias? | + | - | 0

good = all criteria were present "yes"
fair = greater than or equal to 50% of criteria are present
poor = less than 50% of criteria are present or unclear

Evidence Table 2 Risk of bias in observational studies

Author, year | Representativeness of the treated cohort | Selection of the control cohort | Selection of treated patients | Demonstration that outcome of interest was present at start of study | Comparability of cohorts on the basis of the design or analysis | Assessment of outcome | Was followup long enough for outcomes to occur? | Were incomplete outcome data adequately addressed? | RoB score
Banks, 1999^1^ | + | | 0 | + | | 0 | 0 | + | fair
Cheung, 1998^2^ | - | | - | - | | 0 | - | - | poor
Clark 2002^3^ | 0 | | + | + | | 0 | + | - | fair
Dewhurst, 2010^4^ | 0 | 0 | 0 | 0 | | 0 | 0 | 0 | poor
Kumar, 2007^5^ | + | - | + | + | + | 0 | 0 | + | fair
Uga, 2004^6^ | 0 | + | 0 | + | 0 | 0 | + | + | fair
Tanaka, 2007^7^ | + | + | + | + | 0 | 0 | + | 0 | fair
Yadav, , 1999^8^ | - | | + | + | | 0 | 0 | - | poor

KEY
Category | Question | Score
Selection | Representativeness of treated cohort | Truly representative | Somewhat representative | No description
| | + | - | 0
| Selection of control cohort | Same NICU or group of NICUs | Different source | No description
| | + | - | 0
| Selection of treated patients | Medical record | other | no description
| | + | - | 0
| Demonstration that outcoems of interest was not present at start of study | Yes | No | Unclear
| | + | - | 0
Comparability | Comparability of cohorts on the basis of the design or analysis | Yes | No | Unclear
| | + | - | 0
Outcome | Assessment of outcome | Independent blind assessment | record linkage | parent report | teacher report | not description
| | + | + | - | - | 0
| Was follow-up long enough four outcomes to occur? | Yes | Yes for at least 1 outcome of interest | No | Unclear
| | + | + | - | 0
| Were incomplete outcome data adequately addressed | Yes | No | unclear
| | + | - | 0

good = all criteria were present "yes"
fair = greater than or equal to 50% of criteria are present
poor = less than 50% of criteria are present or unclear

Evidence Table 3 Study characteristics

Author, Year | Study Design | Study site-Study location | Recruitment date | Planned length of follow-up | Inclusion criteria | Exclusion criteria | Risk of Bias
Ballard, 2006^1^ | RCT | Multi-Center - North America | Start date: May-2000 – End date: Apr-2005 | 60 Weeks PMA | Age: 7-21 days GA:<= 32 weeks BW: 500-1250 Vent support: "undergoing mechanical ventilation" between 7-21 days of age Other: NCPAP for those with BW 500-799g | Congen: complex anomalies IVH: bilateral grade IV Other: previous iNO exposure | Good
Follow-up of Ballard, 2006^1^ Hibbs, 2007^2^ | RCT | Multi-Center - North America | | 12 Months | Age: 7-21 days of age BW: 500-1250 grams Vent support: required vent support via CPAP or tracheal intubation | | Good
Follow-up of Ballard 2006^1^ Walsh, 2010^3^ | RCT | Multi-Center - North America | | | Age: 7-21 days from birth BW: <1250 g Vent support: intubated and on mechanical ventilation | | Good
Banks, 1999^4^ | Phase II open label, non-controlled pilot study | Single Center - North America | Start date: Oct-1995 – End date: Aug-1997 | | Age: >4 weeks chronologic age FiO2: >/=45% MAP: >/=10mmHg BPD: vent dependent Other: No improvement in resp. status in previous 3 days with optimal use of all standard BPD therapy: glucocorticoids, bronchodilators, diuretics per attending physician | Congen: congenital heart disease | Fair
Cheung, 1998^5^ | Prospective cohort | Single Center - North America | Start date: Dec-1993 – End date: Oct-1997 | Early childhood | GA:24-30 weeks BW: </=1500 grams Hypoxemia: hypoxemia with FiO2 > 90%, and MAP 15+/- 2 | Congen: "congenital anomalies" | Poor
Clark, 2002^6^ | | Multi-Center - North America | Start date: Jun-97 – End date: Jun-99 | 44 wks PMA | Age: < 30 days but > 10 days; BW: <1250; FiO2: > 40% w/o fluctuations of > 25% in the preceding 24 hours; Oligho: clinical and radiographic finding consistent with CLD | Bleeding: Plts<100,000; Congen: CHD, and lethal anomalies; iBetaAnt: if given within preceding 48 hours; IVH: progressive IVH; Corticostrds: initiation of drug within preceding 48 hours; Sepsis: 2 blood cultures yielding single organism in preceding 48 hours
Dani, 2006^7^ | RCT | Single Center - Europe | Start date: Jan-2001 – End date: Jun-2004 | | Age: <=7 days GA:< 30 wks; Inborn RDS: Classic symptoms (need for O2, tachypnea, retractions, and grunting) and typical Xray findings (reduced air content, reticulogranular pattern of lungs and air bronchograms) FiO2: FIO2>0.5 (50%) and arterial-alveolar oxygen ratio <0.15 Surfactant Vent support | Bleeding: Plateletcount <50,000/mm3 and bleeding tendency (hematuria; blood from ETT; gastric aspirate or stools; oozing from puncture sites) Congen: major congenital malformations Hydrops | Fair
Dewhurst, 2010 8 | Retrospecti ve Cohort | Multi-Center - Europe | Start date: Jan-2006 End date: Dec-2007 | | Age: <10 days GA: <31 weeks
Field, 2005^9^ | RCT | Multi-Center - Europe | Start date: Feb-1997 – End date: Dec-2001 | 1 year Corrected age | Age: <28 days GA:<34 weeks Surfactant: treatment if appropriate | Bleeding: Plts <50,000 and PTT>72 sec IVH: Grade 4 IVH Other: severe anomalies; lethal chromosomal anomaly | Poor
Follow-up of Field 2005^9^ Huddy, 2008^10^ | RCT | Multi-Center - Europe | Start date: Feb-1997 – End date: Dec-2001 | 4-5 Years | Age: <28 days GA:<34 wks Respfail: severe Vent support: intubation and mechanical ventilation | | Poor
Franco-Belgium Collaborative NO Trial Group, 1999^11^ | RCT | Multi-Center - Europe | Start date: Apr-1995 – End date: Jun-1997 | Until hospital discharge | Age: <7 days of age GA:<33 weeks OI: 12.5-30 | OI: > the upper limits requiring inhaled nitric oxide; according to the French Drug Agency recommendations Congen: fatal anomalies; cardiac anomalies Dshunting: PDA with severe left to right shunting Hypoxemia: Other forms of pulmonary hypoplasia IVH: grade 3 or 4 Pulmonary hypoplasia: raised pulmonary blood flow Refractory septic shock Other: abnormal neuro exam due to birth asphyxia or grade 3-4 IVH | Fair
Hascoet, 2005^12^ | RCT | Multi-Center - Europe | Start date: Jul-1999 – End date: Feb-2001 | 28 Days | GA:<32 weeks | Bleeding: platelets <50,000/mm3 Congen: major fetal abnormality Hypoxemia: refractory hypoxemia (PO2<50 mmHg & PCO2 <50mmHg on FiO2 100% prior to 6 hours of age) | Fair
Follow-up of Hascoet 2005^12^ Hamon, 2005^13^ | RCT | Single Center - Europe | Start date: Jul-1999 – End date: Feb-2001 | 28 Days | Age: < 48 hours GA:< 32 wks FiO2: > 0.40 Other: aAO2 < 0.22 | Bleeding: Plts < 50,000 Congen: major abnormality Refractory hypoxemia | Fair
Kinsella, 1999^14^ | RCT | Multi-Center - North America | | Hospital discharge | Age: =< 7 days chronological age GA: 34 weeks or less Hypoxemia: Arterial/alveolar oxygen ratio <0.1 on 2 sequential ABGs despite mechanical vent and surfactant Vent Support: mechanical ventilation | Congen: fatal congenital anomaly; congenital heart disease (except ASD; VSD) | Good
Kinsella, 2006^15^ | RCT | Multi-Center - North America | Start date: Mar-2001 — End date: Jun-2005 | | Age: <48 hours GA:<=34 wks BW: 500-1250g Respfail: requiring intubation and mechanical vent Vent Support: intubation & mechanical ventilation | Congen: lethal, congenital heart disease except atrial septal defect <= 1 cm or ventricular septal defect <=2 mm) Pneumothorax: unevaluated Pulmhem: active Vent Support:expected duration of mechanical ventilation of <48 hours | Good
Follow-up of Kinsella 2006 15 Watson, 2009 16 | RCT | Multi-Center - North America | Start date: Mar 2001 — End date: Jun-2005 | 1 Year | Age: <48 hours GA:<=34 weeks BW: 500-1250g Vent Support: mechanical ventilation | Congen: lethal anomalies, CHD Pneumothorax: unevacuated Pulmhem: active hemorrhage Vent Support: expected mechanical ventilation for < 48 hours | Good
Mercier, 2010^17^ | RCT | Multi-center - Europe | Start date: May-2005 End date: May-2008 | 1, 2 and 7 years | GA: <34 weeks
Schreiber, 2003^18^ | RCT | Single Center - North America | Start date: Oct-1998 — End date: Oct-2001 | | Age: <72 hours GA:<34 weeks BW: <2000 g RDS: clinical diagnosis Surfactant: Must be treated with surfactant Vent support: Require intubation and mechanical ventilation | Congen: Major congenital malformations Hydrops | Good
Follow-up of Schreiber, 2003^18^ Mestan, 2005^19^ | RCT | Single Center - North America | Start date: Oct-1998 – End date : Oct-2001 | Two years of age | | | Good
Srisuparp, 2002^20^ | RCT | Single Center - North America | Start date: Jul-1997 – End date: Jan-1998 | Neonatal period, to 28 days of age | Age: < 72 hours BW: <2000g OI: >=4 if birthweight (BW) <= 1000g; >=6 if BW 1001-1250g; >= 8 of BW 1251-1500g; >= 10 if BW 1501-1750 g; >=12 if BW 1751-2000g ArtrCath RDS Vent Support: mechanical ventilation | Congen: major anomalies Hydrops | Poor
Su, 2008^21^ | RCT | Single center - Asia | Start date: Jul-2000 – End date: Jul-2006 | | GA:</= 31 weeks BW: </= 1500g RDS: severe RDS - clinical signs (IC rtxs, flaring, grunting) or CXR findings severe diffuse reticulogranular infiltrates w/low lung volumes Respfail: OI >/=25 Vent Support: mechanical ventilation | Bleeding: uncorrectable Congen: severe congenital abnormalities IVH: Severe III or IV Other: lethal chromosomal anomalies | Fair
Subhedar, 1997^22^ | RCT | Single Center - Europe | Start date: Aug-1995 – End date: Sep-1996 | Not specified in article | Age: 96 hours of age GA:<32 weeks RDS: requiring mechanical ventilation Surfactant Vent Support: mechanically ventilated since birth Other: high risk for CLD by prediction score | Bleeding: Plts< 50 Congen: major anomalies; structual cardiac anomalies Dshunting:significant IVH: with parenchymal involvement Pulmhem Sepsis: Culture positive Other: GI bleed | Poor
Follow-up of Subhedar, 1997^22^ Bennett, 2001 23 | RCT | Single Center - Europe | | 30 Months corrected age | GA:<32 weeks | Intrprncyml: parenchymal involvement at trial entry | Poor
Tanaka, 2007^24^ | Retrospecti ve cohort | Single Center - Asia | Start date: Jan-1988 – End date: Dec-1999 | 3 Years | GA:< 34 weeks Shuting: Rt-to-L shunt at PDA or R-to-L at arterial level Hypoxemia: due to PPHN PPHN: Clinical: >5% difference in Pre- & Post-ductal SaO2, or recurrent desats <85% over 12hours despite optimal treatment of lung disease, AND Echo evidence (w/o structural heart disease): peak systolic PAP >35mmHg or >2/3 systemic systolic pressure - indicated by R-to-L shunting at PDA or arterial level | Multiple birth: Singleton only Congen: No structural heart disease | Fair
Uga, 2004^25^ | Retrospective cohort | Single Center - Asia | Start date: Jan-1999 End date: NS | NS | BW: <1500 grams FiO2: 100% MAP: >8 Oligho: >5 days with PROM PPHN: defined by no response to surfactant, oligohydramnios/PROM>5 days, refractory hypoxemia PROM: >5 days Respfail: insufficient arterial oxygenation on 100% FiO2, MAP >8cmH20 Surfactant: with no response
Van Meurs, 2005^26^ | RCT | Multi-Center -North America | Start date: Jan-2001 – End date: Sep-03 | | Age: 4 to 120 hours after birth GA:< 34 weeks BW: 401-1500g OI: at least 10 on 2 ABGs between 30 min and 12 hours apart; revised to OI of at least 5.0 followed within 30 min to 12 hours of OI of at least 7.5 ArtrCath: eligible from 4 to 120 hours after birth Congen: Ventricular Septal Defect, patent ductus arteriosus and atrial level shunt permitted PPHN: idiopathic Pneumonia Pulmonary hypoplasia: suspected RDS Sepsis Surfactant: at least 4 hours before Vent Support: required assisted ventilation Other: Aspiration | Bleeding: Bleeding diathesis or platelet count at or below 50,000 per cu. mm. (thrombocytopenia) Congen: Congenital Heart Disease, major congenital anomaly involving respiratory system | Good
Sub analysis of Van Meurs, 2005^26^ Chock, 2009^27^ | RCT | Multi-Center – North America | Start date: Jan-2001 – End date: Sep-2003 | 18 to 22 Months | GA:<34 wks; <34 wks BW: 401-1500g (iNO trial); some >1500g (larger Preemie Pilot study) Oligho: documented on U/S 5+ days prior to delivery Pulmhyp: interpretation of CXR w/small, hypoplastic appearing lungs Respfail: 4 hours following surfactant
Follow-up of Van Meurs, 2005^26^ Hintz, 2007^28^ | RCT | Multi-Center - North America | Start date: Jan-2001 – End date: Sep-03 | 18 - 22 Months corrected age | GA:< 34 wks BW: 401 - 1500 g OI: >/=10 on 2 consecutive blood gases 30 min to 12 h apart; revised to OI >/=5 followed by OI>/=7.5 w/in 30 min to 24 hours Respfail: severe (defined in original iNO trial) Surfactant:x1 dose at least 4hr before meeting OI criteria Vent support: Mechanical | | Good
Van Meurs, 2007^29^ | RCT | Multicenter - North America | Start date: Jan-2001 – End date: Sep-2003 | 18-22 Months | GA:<34 wks BW: >1500 g OI: OI >/=15 ×2 ABGs 30 min-12 hrs apart; OI >/=10 then OI>/=12.5 within 30 min-24 hrs PPHN: idiopathic Pneumonia Pulmonary hypoplasia Sepsis RDS Surfactant: at least 1 dose >4hrs prior Vent Support: mechanical ventilation Other: Aspiration syndromes | Bleeding: Platelets <50,000; or bleeding diathesis Congen heart disease Other: decision not to provide full treatment | Good
Yadav, 1999^30^ | Retrospective cohort | Single Center - Europe | Start year: 1993 – End year: 1997 | Hospital discharge | GA: "preterm" Hypoxemia: "severe hypoxemia despite max therapy | Congen: major malformation; | Poor

ArtrCath: Arterial catheter, BPD: Bronchopulmonary dysplasia , BW: Birth weight, Congen: Congenital anomaly/malformation, Dshunting: Ductal Shunting, FiO2: Fraction of Inspired Oxygen, g:grams, GA: Gestational age, iNO: inhaled Nitric Oxide, intrprncyml:Intraparenchymal lesion, IVH: Intraventricular Hemorrhage, MAP: Mean airway pressure, OI: Oxygenation Index, Oligho : Oligohydramnios, PMA: post menstrual age, PPHN: Persistent Pulmonary Hypertension of the Newborn, Pulmhyp: Pulmonary hypoplasia, RDS: Respiratory distress syndrome, Respfail: Respiratory failure , Vent Support: Ventilation Support

Evidence Table 4 Participant Characteristics

Author, year | Control Interventions | N at baseline | Gestational age (weeks) | Birth weight (grams) | Race n(%) | Mode of Ventilation, n(%) | Participant age at enrollment | Oxygenation Index | iNO Dose | iNO Duration
Ballard, 2006^1^ | Placebo | 288 | Mean: 26 SD: 1.5 | Mean: 759 SD: 155 | W: 145 (50.3) B: 90 (31.3) H: 43 (14.9) Other: 10 (3.) | HFV: 74 (25.7) CMV: 191 (66.3) CPAP: 23 (8) | Median:16 Range:13-19 IQR Units: Days | NA
Ballard, 2006^1^ | iNO | 294 | Mean: 26 SD: 1.5 | Mean: 766 SD: 161 | W: 170 (57.8) B: 76 (25.9) H: 32 (10.9) Other: 16 (5.4) | HFV: 65 (22.1) CMV: 202 (68.7) CPAP: 27 (9.2) | Median:16 Range:12-19 IQR Units: Days | NA | 20ppm ×48-96hours: titrate every 7days for a minimum of 2 days exposure
Follow-up of Ballard, 2006^1^ Hibbs, 2007^2^ | Placebo | 225 | Mean: 25.7 SD: 1.5 | Mean: 762 SD: 150 | W: 121 (53.8) B: 64 (28.4) H: 31 (13.8) Other: 9 (4) | NA | NA | NA
Follow-up of Ballard, 2006^1^ Hibbs, 2007^2^ | iNO | 230 | Mean: 25.8 SD: 1.4 | Mean: 769 SD: 163 | W: 141 (61.3) B: 56 (24.2) H: 22 (9.5) Other:: 11 (4.8) | NA | NA | NA | 20ppm: weaned over at least 24days
Follow-up of Ballard 2006^1^ Walsh, 2010^3^ | Placebo gas | 234 | Mean: 25.7 SD:1.5 | Mean: 764 SD: 153 | W: 124(53) Other: 110(47) | NA | Median: 16 Range: 13-20 IQR Unit: days | NA
Follow-up of Ballard 2006^1^ Walsh, 2010^3^ | iNO | 243 | Mean:25.8 SD: 1.4 | Mean: 765 SD: 163 | W: 151(62) Other: 92(38) | NA | Median: 17 Range: 13-19 IQR Unit: days | NA | 20ppm ×24hours: decrease to 10ppm ×1week decrease to 5ppm ×1week decrease to 2ppm ×1week
Banks, 1999^4^ | iNO | 16 | Median: 25.5 Range: 24-29 | Median: 787 Range: 448-1790 | NA | HFV: 5 (31.25) CMV :11 (68.75) | Median: 2.5 Range: 1-7 Units: Months | NA | 20ppm ×72hours: responders weaned by 20% every 3day
Cheung, 1998^5^ | iNO treated cohort | 24 | Median: 25 Range: 24-27 (25% and 75 %) | Median: 860 Range: 668-1068 (25% and 75 %) | NA | CMV : 24 (100) | NA | Median:32 Range: 28-52 (25% and 75 %) | 20ppm: decrease by 5ppm within 2hours s/p initial dose decrease by 5ppm q15-30min to lowest dose w/+ response
Clark, 2002^6^ | iNO | 33 | Mean: 25.3; Range: 23-29 | Mean: 736 Range: 509-1250 | W: 11 (33) B: 21 (64) H: 1 (3) | | Mean: 19 Range: 9-29 Units: Days | | 20ppm ×36hours: decrease to 15ppm and decrease by 2-3ppm every1 2hours; discontinued by 7 days.
Dani, 2006^7^ | Control | 20 | Mean: 26.7 SD: 1.9 | Mean: 825 SD: 299 | NA | HFV: 11 (55) | NA | Mean: 15.1 SD: 4.9
Dani, 2006^7^ | iNO | 20 | Mean: 26.3 SD: 2.6 | Mean: 937 SD: 298 | NA | HFV: 10 (50) | NA | Mean:16.4 SD: 5.1 | 5ppm: Increase by 5ppm every 30min to max 15ppm
Dani, 2006^7^ | No responders | 6 | Mean: 25.4 SD: 2.6 | Mean: 748 SD: 321.4 | NA | CPAP: 4 (67) | NA | Mean:18.1 SD: 4.2 | 5ppm: Increase by 5ppm every 30min to max 15ppm
Dani, 2006^7^ | Responders | 14 | Mean: 26.7 SD: 1.9 | Mean: 1022.7 SD: 243.1 | NA | CPAP: 13 (93) | NA | Mean:14.7 SD: 3.9 | 5ppm: Increase by 5ppm every 30min to max 15ppm
Dewhurst, 2010^8^ | Responders | 26 | Median: 26 Range: 25-29 | Median: 920 Range: 655-1538 | NA | | Median: 53 Range: 37-217 Units: Hours | Median: 47 Range: 30-78 | 10ppm: titrated
Dewhurst, 2010^8^ | Non-responders | 8 | Median: 29 Range: 27-30 | Median: 915 Range: 723-183 | NA | | Median: 75 Range: 20-183 Units: Hours | Median: 23 Range: 8-54 | 20ppm: titrated
Field, 2005^9^ | Control | 53 | Mean: 26.3 SD: 2.4 | Mean: 890 SD: 343 | NA | HFV: 39 (74%) | Median: 1 Range: 1-5 IQR Units: Days | Median:31.9 Range: 17.4-51.8 IQR
Field, 2005^9^ | iNO | 55 | Mean: 27.4 SD: 2.6 | Mean: 1006 SD: 395 | NA | HFC: 33 (60) | Median: 1 Range: 0-6 IQR Units: Days | Median: 32.9 Range: 22.2-49.8 IQR, | 5ppm: double dose every 15min to max 40ppm
Follow-up of Field 2005^9^ Huddy, 2008^10^ | Control | 16 | Mean: 28.2 SD: 2.7 | Mean: 1142 SD: 440 | NA | NA | Median: 1 Range: IQR 1.5 Units: Days | Median: 25.9 Range: IQR 41.3
Follow-up of Field 2005^9^ Huddy, 2008^10^ | iNO | 22 | Mean: 28.5 SD: 2.4 | Mean: 1191 SD: 403 | NA | NA | Median: 1 Range: IQR 3 Units: Days | Median: 30.1 Range: IQR 20.5 | 5ppm: double dose every 15min until PaO2 increases >22.5mmHg to max 40ppm
Franco-Belgium Collaborativ e NO Trial Group, 1999^11^ | Control | 45 | Median: 29 Range: 3.1 IQR | Median: 1150 Range: 520 IQR | NA | HFV: 34 (76) CMV : 11 (24) | Median:1 Range: 1 IQR Units: Days | Median: 18 Range: 7.4 IQR
Franco-Belgium Collaborativ e NO Trial Group, 1999^11^ | iNO | 40 | Median: 29.6 Range: 2.6 IQR | Median: 1200 Range: 570 IQR | NA | HFV: 30 (75) CMV : 10 (25) | Range: 1.5 Units: Days | Median:20.2 Range: 8.3 IQR | 10ppm ×2-3hours: decreased to 5ppm then slowly wean off if deteriorating condition, increased dose to 20ppm
Hascoet, 2005^12^ | Control with hypoxemic respiratory failure | 84 | NA | BW<750: 19 (22) BW 750-999: 17 (20), BW 1000-1500: 32 (39) BW >1500: 16 (19) | NA | NA | NA | Mean:12 SD: 5.6
Hascoet, 2005^12^ | iNO with hypoxemic respiratory failure | 61 | NA | BW <750g: 10 (16.5) BW 750-999g: 14 (23) BW 1000-1500g: 27 (44) BW >1500g: 10 (16.5) | NA | NA | NA | OI Mean:14.6 SD: 8.9 | 5ppm: if aAO2 increase >0.22 decrease iNO to 2ppm if aAO2 increase <0.22 but >25% iNO remains at 5ppm if aAO2 unchanged increase iNO to 10ppm
Follow-up of Hascoet 2005^12^ Hamon, 2005^13^ | Hypoxemic respiratory failure, no iNO | 39 | Mean: 27.9 SD: 0.4 | Mean: 1102 SD: 54 | NA | NA | Mean:15.9 SD: 1.8 Units: Hours | NA
Follow-up of Hascoet 2005^12^ Hamon, 2005^13^ | iNO treated hypoxemic respiratory failure | 37 | Mean: 27.3 SD: 0.4 | Mean: 1083 SD: 58 | NA | NA | Mean:14.1 SD:1.4 Units: Hours | NA | 5ppm: aAO2 increase >0.22 decrease iNO to 2ppm aAO2 increase <0.22 but >25% iNO remains at 5ppm aAO2 unchanged increase iNO to 10ppm | Median: 35.1 hours
Kinsella, 1999^14^ | Control | 32 | Mean: 26.8 SD: 2.5 | Mean: 988 SD: 387 | NA | NA | Mean: 27 SD:37 Units: Hours | NA
Kinsella, 1999^14^ | iNO | 48 | Mean: 27.1 SD: 2.5 | Mean: 1040 SD: 461 | NA | NA | Mean:30 SD: 38 Units: Hours | NA | 5ppm × 7days: if OI increase >15%, iNO restarted
Kinsella, 2006^15^ | Placebo gas, Total sample | 395 | Mean: 25.6 SD: 1.8 | Mean: 788 SD: 185 | W: 234 of 394 (59.4) B: 98 of 394 (24.9) H: 48 of 394 (12.2) Other: 14 of 394 (3.6) | HFV: 113 of389 (29) CMV : 276 of 389 (71) | Mean:30.1 SD:13.2 Units: Hours | Mean:5.8, SD:6.7
Kinsella, 2006^15^ | iNO, Total sample | 398 | Mean: 25.6 SD: 1.7 | Mean: 796 SD: 190 | W: 249 of 397(62.7) B: 94 of 397(23.7) H: 41 of 397(10.3) Other: 13 of 397 (3.3) | HFV: 113 of 393 (28.8) CMV : 280 of 393 (71.2) | Mean:30.5 SD:13.4 Units: Hours | Mean:5.4 SD: 5.2 | 5ppm × 21days | Median: 14 days
Follow-up of Kinsella 2006^15^ Watson, 2009^16^ | Control-detailed outcome cohort | 320 | Mean: 25.7 SD: 1.9 | Mean: 791 SD: 186 | W: 192 (60) B: 71 (22.2) H: 44 (13.8) Asian/Other: 13 (4.1) | NA | NA | Median:4.1 Range: 2.7-6.4 IQR
Follow-up of Kinsella 2006^15^ Watson, 2009^16^ | iNO-detailed outcome cohort | 332 | Mean: 25.6 SD: 1.7 | Mean: 797 SD: 190 | W: 205 (61.8) B: 76 (22.9) H: 38 (11,5) Asian/Other: 13 (3.9) | NA | NA | Median:4.1 Range: 2.8-6.2 IQR | 5ppm ×21days or until extubated
Mercier, 2010^17^ | Control | 401 | Mean: 26.6 SD: 1.3 | Mean: 864 SD: 192 | W: 328 (82) B: 48 (12) A: 2 (<1) Other: 23 (6) | CPAP: 42 (10) | NA | Mean: 8.6 SD: 12.7 | 5ppm
Mercier, 2010^17^ | iNO | 399 | Mean: 26.4 SD: 1.3 | Mean: 851 SD: 207 | W: 329 (82) B: 39 (10) A: 4 (1) Other: 27 (7) | CPAP: 41 (10) | NA | Mean: 8.0 SD: 10.7 | 5ppm
Schreiber, 2003^18^ | Placebo | 102 | Mean: 27 SD: 2.8 | Mean: 949 SD: 387 | W: 12 (11.8) B: 74 (72.6) Other: 16 (15.7) | HFV: 48 (47) CMV: 54 (52.9) | Median:114 Range: IQR 7.6-28.5 | Median:6.8 Range: 4.4-12.7 IQR
iNO | | 105 | Mean: 27.4 SD: 2.5 | Mean: 1017 SD: 369 | W: 18 (17.1) B: 71 (67.6) Other: 16 (15.2) | HFV: 54 (51.4) CMV: 51 (48.6) | Median: 12.9 Range: IQR 7.0-25.2 | Median:7.3 Range: IQR 4.1-12.3 | 10ppm ×12-24hours: decrease to 5ppm and hold 6day or 1 hour before extubation if Pa02 decrease by 15%, restart NO and decrease by 1 ppm every 6hours
Follow-up of Schreiber, 2003^18^ Mestan, 2005^19^ | Control | 68 | Mean: 27.2 SD: 2.6 | Mean: 958 SD: 356 | W: 8 (12) B: 52 (76) Other:: 8 (12) | NA | SD: 8.4 Units: Months | Median: 7.2 Range: IQR 4.5-14.3
Follow-up of Schreiber, 2003^18^ Mestan, 2005^19^ | iNO | 70 | Mean: 27.5 SD: 2.4 | Mean: 1026 SD: 366 | W: 14 (20) B: 44 (63), Other:: 12 (17) | NA | Mean: 24.9 SD: 7.9 Units: Months | Median: 6.6 Range: IQR 4-11.5 | 10ppm ×24hours: decrease to 5ppm and hold 6d or 1 hours before extubation
Srisuparp, 2002^20^ | Control | 18 | Mean: 27.2 SD: 0.5 | Mean: 901 SD: 73 | B: 16 (89) | HFV: 7 (38.9) | NA | Mean:11.9 SD: 2.2
Srisuparp, 2002^20^ | iNO | 16 | Mean: 26.8 SD: 0.5 | Mean: 874 SD: 70 | B: 16 (100) | HFV: 7 (43.8) | NA | Mean:10.8 SD: 1.5 | 20ppm ×6-12hours: decrease to 10ppm ×12hours decrease to 5ppm ×12hours decrease by 1ppm every 12hours
Su, 2008^21^ | Received inhaled oxygen placebo only | 33 | Mean: 27.9 SD: 1.8 | Mean: 1050 SD: 210 | NA | NA | Mean:2.5 SD: 1.8 Units: Days | Mean: 30.5 SD: 4.7
Su, 2008^21^ | iNO | 32 | Mean: 27.4 SD: 2.3 | Mean: 1020 SD: 230 | NA | CMV : 32(100) | Mean: 2.45 SD: 1.7 Units: Days | Mean:30.3 SD: 3.5 | 5ppm ×6hours: if + response, decrease 1ppm every 6hours to min 1ppm if – response, increase 5ppm every 6hours to max. 20ppm | Mean: 4.9 SD: 2.3 Unit: days
Subhedar, 1997^22^ | Dexamethasone and standard of care | 22 | Median: 27 Range: 22-31 | Median: 750 Range: 520-1400 | NA | NA | Median: 104 Range: 96-120 Units: Hours | Median: 3.9 Range: 1.2-11.5
Subhedar, 1997^22^ | iNO + iNO and dexamethasone) | 20 | Median: 27 Range: 24-30 | Median: 882 Range: 416-1354 | NA | NA | Median: 99 Range: 96-113 IQR Units: Hours | Median: 7.9 Range: 1.6-46.7 | 20ppm: iNo started at 20ppm, given for 2 hours, if responsive weaned by 5 ppm every 15 minutes until 5ppm then continued for 72 hours, then discontinued.
Subhedar, 1997^22^ | Dexamethasone alone AND dex + iNO) | 21 | Median: 27 Range: 22-31 | Median: 870 Range: 530-1400 | NA | NA | Median: 104 Range: 96-120 Units: Hours | Median: 7.9 Range: 1.2-46.7 | 20ppm: iNo started at 20ppm, given for 2 hours, if responsive weaned by 5 ppm every 15 minutes until 5ppm then continued for 72 hours, then discontinued.
Subhedar, 1997^22^ | iNO AND standard of care | 21 | Median: 27 Range: 22-31 | Median: 818 Range: 520-1222 | NA | NA | Median: 98 Range: 96-114 Units: Hours | Median: 4.1 Range: 1.4-28 | 20ppm: iNo started at 20ppm, given for 2 hours, if responsive weaned by 5 ppm every 15 minutes until 5ppm then continued for 72 hours, then discontinued. | `
Follow-up of Subhedar, 1997^22^ Bennett, 2001^23^ | Control | 22 | NA | NA | NA | CMV :22 (100) | Mean: 96 Units: Hours | NA
Follow-up of Subhedar, 1997^22^ Bennett, 2001^23^ | iNO | 20 | NA | NA | NA | CMV :20 (100) | Mean: 96 Units: Hours | NA | 5-20ppm iNO × 72hours or until extubated
Tanaka, 2007^24^ | Control | 15 | Median: 26 Range: 24-30 | Median: 818 Range: 720-1400 IQR | NA | HFV: 9 (60) | NA | Median: 23.3 Range: 16-45
Tanaka, 2007^24^ | iNO | 16 | Median: 25.5 Range: 25-28.8 | Median: 838 Range: 628-1144 IQR | NA | HFV: 14 (87.5) | NA | Median: 23.3 Range: 16-45 IQR | 10ppm: Increase 10ppm every 30min to max 30ppm
Uga, 2004^25^ | Control | 10 | Mean: 25.8 SD: 2.4 Range: 24-30 | Mean: 809 SD: 316 Range: 426-1453 | NA | NA | NA | Mean: 13.9 SD: 10.2
Uga, 2004^25^ | iNO | 8 | Mean: 27.2 SD: 2.2 Range: 24-30 | Mean: 996 SD: 294 Range: 570-1317 | NA | NA | NA | Mean: 28.8 SD: 18.3 | 30-40ppm
Van Meurs, 2005^26^ | Control | 210 | Mean: 26 SD: 2 | Mean: 837 SD: 260 | W: 96 (46) B: 78 (37) H: 32 (15) Other: 4 (2) | HFV: 124 (59) CMV: 86 (41) | Mean:28 SD: 22 Units: Hours | Mean:22 SD:17
Van Meurs, 2005^26^ | iNO | 210 | Mean: 26 SD: 2 | Mean: 840 SD: 264 | W: 95 (45) B: 69 (33) H: 36 (17) Other: 10 (5) | HFV: 125 (59) CMV : 85 (40) | Mean:26 SD: 23 Units: Hours | Mean:23 SD:17 | 5ppm: Hold if PaO2 increases >=20mmHg or increase to 10ppm | Mean: 76 SD: 73 Unit: hours
Sub analysis of Van Meurs, 2005^26^ Chock, 2009^27^ | Control | 6 | Mean: 29 SD: 3 | Mean: 1179 SD: 369 | W: 4 (67) B: 1 (17) H: 0 (0) Other: 1 (17) | HFV: 6 (100) | Mean:11 SD: 4 Units: Hours | Mean:44 SD: 30 Median:39 Range:10-100
Sub analysis of Van Meurs, 2005^26^ Chock, 2009^27^ | iNO | 6 | Mean: 27 SD: 2 | Mean: 1039 SD: 355 | W: 2 (33) B: 1 (17) H: 2 (33) Other: 1 (17) | HFV: 6 (100) | Mean:12 SD: 8 Units: Hours | Mean:20 SD:27 Median: 19 Range: 11-64 | 5ppm ×30min: increase 5ppm if PaO2 did not increase >20mmHg | Mean: 1 SD: 0.2 Unit: hours
Follow-up of Van Meurs, 2005^26^ Hintz, 2007^28^ | Placebo | 102 | Mean: 26.2 SD: 2.2 | Mean: 864 SD: 271 | W: 46 (45) B: 35 (34) H: 18 (18) Other: 1 (1) | HFV: 57 (56) | NA | Mean: 18.1 SD:1 1.3 Median: 149 Range:.5 - 21.6 | | Median: 2 Range: 1-75 IQR Unit: hours
Follow-up of Van Meurs, 2005^26^ Hintz, 2007^28^ | iNO Follow-up of group | 91 | Mean: 26.8 SD: 2.3 | Mean: 958 SD: 276 | W: 43 (47) B: 27 (30) H: 17 (19) | HFV: 61 (67) | NA | Mean: 20 SD:12.9 Median: 16.3 Range: 12-24 | 5ppm titrated | Median:72 Range: 42-115IQR
Van Meurs, 2007^29^ | Control | 15 | Mean: 31.4 SD: 1.1 | Mean: 2168 SD: 441 | W: 5 (33) B: 4 (27) H: 6 (40) | HFV: 11 (73) CMV : 2(13) HFFI: 2 (13) | NA | Mean: 28.2 SD:17.3
Van Meurs, 2007^29^ | iNO | 14 | Mean: 31.1 SD: 1.2 | Mean: 1970 SD: 391 | W: 7 (50) B: 5 (36) H: 1 (7) Other:1 (7) | HFV: 6 (43) CMV : 8 (57) HFFI 0 (0) | NA | Mean:25.1 SD:19.4 | 5ppm ×30min: Increase to 10ppm
Yadav, 1999^30^ | iNO | 41 | Mean:27 SD:2.6 | Mean: 1000 SD: 46 | NA | NA | NA | Mean: 40 SD: 17 | 10ppm

B:Non-hispanic black; H:Hispanic; W:non-hispanic white; HFV: High-frequency ventilation; CMV: Conventional mechanical ventilation; CPAP: Continuous Positive Airway Pressure; HFFI: High-frequency flow interruption; mmHg: millimeters of mercury; ppm: parts per million; iNO: inhaled nitric oxide

Evidence Table 5 Death and survival outcomes for KQ1

Author, Year | Outcome | Time of outcome measure | Arm Description | N (Number of Participants Measured) | Participants with Outcome n (%) | Relative Effect (95% CI) OR (95% CI) | Adjusted Relative Effect (95% CI) Adjusted OR (95% CI) | Adjustments
Ballard, 2006^1^ | Death | 36 weeks PMA | Control | 288 | 18 (6.3)
Ballard, 2006^1^ | Death | 36 weeks PMA | iNO | 294 | 16 (5.4)
Ballard, 2006^1^ | Death | 40 weeks PMA | Control | 288 | 19 (6.6)
Ballard, 2006^1^ | Death | 40 weeks PMA | iNO | 294 | 19 (6.5)
Ballard, 2006^1^ | Death | 44 wks PMA | Control | 288 | 20 (6.9)
Ballard, 2006^1^ | Death | 44 wks PMA | iNO | 294 | 20 (6.8)
Dani, 2006^2^ | Death | NICU | Control | 20 | 6 (30) | | P-value: 0.494 | birth weight
Dani, 2006^2^ | Death | NICU | iNO | 20 | 4 (20) | | P-value: 0.494 | birth weight
Dani, 2006^2^ | Death | NICU | Nonresponders | 6 | 4 (66) | P-value: 0.078
Dani, 2006^2^ | Death | NICU | Responders | 14 | 3 (21) | P-value: 0.078
Field, 2005^3^ | Death | 1 year | Control | 53 | 34 (64)
Field, 2005^3^ | Death | 1 year | iNO | 55 | 30 (55)
Franco-Belgium Collaborative NO Trial Group, 1999^4^ | Death | in NICU | Control | 45 | 16 (35) | P-value: Not significant
Franco-Belgium Collaborative NO Trial Group, 1999^4^ | Death | in NICU | iNO | 40 | 11 (27)
Hascoet, 2005^5^ | Death | 7 days of life | Control with HRF | 84 | 14 (17) | P-value: 0.58 | 1
Hascoet, 2005^5^ | Death | 7 days of life | iNO with HRF | 61 | 8 (13) | P-value: 0.58 | 1
Hascoet, 2005^5^ | Death | 28 days of life | Control with HRF | 84 | 26 (31) | P-value: Not significant
Hascoet, 2005^5^ | Death | 28 days of life | iNO with HRF | 61 | 25 (41)
Kinsella, 1999^6^ | | Discharge | Control | 32 | 17 (53) | P-value: 0.65 RR: 1.11(0.7-1.8)
Kinsella, 1999^6^ | | Discharge | iNO | 48 | 23 (48)
Kinsella, 2006^7^ | | 36 wks PMA | Control | 392 | 98 (25) | | P-value: 0.08 RR: 0.79 (0.61-1.03) | randomization strata, study sight
Kinsella, 2006^7^ | | 36 wks PMA | iNO, Total sample) | 394 | 78 (19.8)
Mercier, 2010^8^ | | 24-28 weeks | Control | 401 | 42 (10.5)
Mercier, 2010^8^ | | 24-28 weeks | iNO | 399 | 56 (14)
Schreiber, 2003^9^ | | NICU | Control | 102 | 23 (22.5) | P-value: 0.18 RR: 0.68 (0.38-1.20) | RR: 0.68 (0.38-1.20) | type of ventilation
Schreiber, 2003^9^ | | NICU | iNO | 105 | 16 (15.2)
Srisuparp, 2002^10^ | | 7 days | Control | 22 | 2 (11.1) | P-value: 1
Srisuparp, 2002^10^ | | 7 days | iNO | 16 | 2 (12.5)
Su, 2008^11^ | | During Study (9 death within 96 hours) | Control | 33 | 10 (30.3)
Su, 2008^11^ | | During Study (9 death within 96 hours) | iNO | 32 | 6 (18.8)
Su, 2008^11^ | | During Study (9 death within 96 hours) | groups 1&3; iNO + iNO and dexamethasone) | 20 | 10 (50)
Van Meurs, 2005^13^ | | death before discharge to home or within 365 | Control | 208 | 93 (45) | | P-value: 0.11 RR: 1.16 (0.96-1.39) | Birthweight, study center, OI
Van Meurs, 2005^13^ | | death before discharge to home or within 365 | iNO) | 210 | 109 (52)
Van Meurs, 2007^14^ | | Death before discharge to home or within 365 | Control | 15 | 4 (27) | P-value: 0.7 RR: 1.34 (0.45-4.0) | p-value: 0.65 RR: 1.26 (0.47-3.41) | OI Stratum
Van Meurs, 2007^14^ | | Death before discharge to home or within 365 | iNO | 14 | 5 (36)
Ballard, 2006^1^ | Survival without BPD | 36 weeks PMA | Control | 288 | 105 (36.5) | p-value:0.04 RR: 1.26 (1.02-1.55) | RR: 1.45 (1.03-2.04) | cluster (multiples) using GEE; from the letter to the editor correction
Ballard, 2006^1^ | Survival without BPD | 36 weeks PMA | iNO | 294 | 129 (43.9)
Hascoet, 2005^5^ | | 28 days | Control with HRF | 84 | 18 (21.4) | p-value:NS
Hascoet, 2005^5^ | | 28 days | iNO with HRF | 61 | 14 (23) | p-value:NS
Schreiber, 2003^9^ | | Survived NICU | iNO | 89 | 54 (60.7)
Schreiber, 2003^9^ | | Survived NICU | Control | 79 | 37 (46.8)
Schreiber, 2003^9^ | Survival with BPD | Survived NICU | Control | 102 | 42 (53.2) | p-value:0.07 RR:0.74 (0.53-1.03)
Schreiber, 2003^9^ | Survival with BPD | Survived NICU | iNO | 105 | 35 (39.3)
Schreiber, 2003^9^ | Survival with BPD | Survived NICU | iNO | 105 | 35 (39.3)
Subhedar, 1997^12^ | Survival with BPD | Not Specified | Control dexamethasone and standard of care | 22 | 14 (64) | RR: 1.07 (0.71-1.37) RR: 0.92 (0.67-1.28)
Subhedar, 1997^12^ | Survival with BPD | Not Specified | Groups 1&3; iNO + iNO and dexamethasone | 10 | 10 (100)
Subhedar, 1997^12^ | Survival with BPD | Not Specified | Dexamethasone alone AND dex + iNO | 21 | 11 (52)
Subhedar, 1997^12^ | Survival with BPD | Not Specified | iNO AND standard of care | 21 | 13 (62)
Schreiber, 2003^9^ | Survival, BPD not specific | Survived NICU | Control | 102 | 79 (77.5)
Schreiber, 2003^9^ | Survival, BPD not specific | Survived NICU | iNO | 105 | 89 (84.8)

BPD: Bronchopulmonary Dysplasia, CI: Confidence Interval, GEE: Generalized estimating equation, HRF: Hypoxemic Respiratory Failure , iNO: Inhaled nitric oxide, NICU: Neonatal intensive care unit, NS: Not significant, OI: Oxygenation Index, OR: Odds ratio, PMA: Post-menstrual age , RR: Relative risk

Evidence Table 6 BPD for KQ1

Author, Year | Time of outcome measure | Study Arm | N (number of participants measured) | Participants with Outcome—n (%) | Relative Effect (95% CI) | Adjusted Relative Effect (95% CI) | Adjustments | Duration (days) | Difference in Duration (p-value)
Ballard, 2006^1^ | 36 weeks PMA | Control | 288 | 164 (56.9)
Ballard, 2006^1^ | 36 weeks PMA | iNO | 294 | 149 (50.7)
Dani, 2006^2^ | 36 weeks PMA | Control | 20 | 12 (60) | P-value: 0.067 | | | Mean: 69.4 SD: 30.2 | 0.054
Dani, 2006^2^ | 36 weeks PMA | iNO | 20 | 6 (30) | | | | Mean: 47.3 SD: 39.4
Dani, 2006^2^ | 36 weeks PMA | Nonresponders | 6 | 2 (33) | | | | Mean: 19.8 SD: 11.5 | 0.084
Dani, 2006^2^ | 36 weeks PMA | Responders | 14 | 7 (50) | | | | Mean: 48.6 SD: 37.3
Field, 2005^3^ | 36 weeks PMA | Control | 55 | 15 (27) | | | | Mean: 6 IQR:1.0-17.0
Field, 2005^3^ | 36 weeks PMA | iNO | 53 | 26 (49) | | | | Mean: 15 IQR:2-71
Franco-Belgium Collabor ative NO Trial Group, 1999^4^ | during hospitalization | Control | 29 | 8 (29) | p-value: NS | | | Median: 23 IQR:41 | 0.38
Franco-Belgium Collabor ative NO Trial Group, 1999^4^ | during hospitalization | iNO | 29 | 7 (24) | p-value: NS OR: 0.95 (0.44–2.04) | | | Median: 14 IQR:43
Kinsella, 2006^5^ | 36 weeks PMA | Control | 309 | 210 (68) | P-value: 0.43 | RR:0.96 (0.86–1.09) | randomizati on strata, study sight
Kinsella, 2006^5^ | 36 weeks PMA | iNO | 326 | 212 (65) | P-value: 0.43 | RR:0.96 (0.86–1.09) | randomizati on strata, study sight
Kinsella, 1999^6^ | 36 weeks PMA | Control | 15 | 12 (80) | p-value: 0.3 RR: 0.75(0.5-1.13)
Kinsella, 1999^6^ | 36 weeks PMA | iNO | 25 | 15(60) | p-value: 0.3 RR: 0.75(0.5-1.13)
Mercier, 2010^7^ | 24-28 weeks | Control | 358 | 96 (27)
Mercier, 2010^7^ | 24-28 weeks | iNO | 339 | 81(24)
Schreiber, 2003^8^ | 36 weeks PMA | Control | 102 | 42 (53.2) | | P-value: 0.07 RR: 0.74 (0.53–1.03) | type of ventilation
Schreiber, 2003^8^ | 36 weeks PMA | iNO | 105 | 35 (39.3)
Su, 2008^9^ | 36 weeks PMA | Control | 33 | 11 (33.3)
Su, 2008^9^ | 36 weeks PMA | iNO | 32 | 10 (31.3)
Subhedar, 1997^10^ | 36 weeks PMA | Dexamethas one and standard of care | 22 | 14 (64)
Subhedar, 1997^10^ | 36 weeks PMA | Groups 1&3; iNO + iNO and dexamethas one | 20 | 10 (50)
Subhedar, 1997^10^ | 36 weeks PMA | Dexamethas one alone AND dex + iNO | 21 | 11 (52)
Subhedar, 1997^10^ | 36 weeks PMA | iNO AND standard of care | 21 | 13 (62)
Van Meurs, 2007^11^ | 36 weeks PMA | Control | 11 | 5 (45) | p-value: 0.66 RR: 0.66 (0.21-2.08) | p-value: 0.21 RR: 0.40 (0.09-1.71) | OI stratum | Mean: 32 SD: 23 | 0.45
Van Meurs, 2007^11^ | 36 weeks PMA | iNO | 10 | 3 (30) | p-value: 0.66 RR: 0.66 (0.21-2.08) | p-value: 0.21 RR: 0.40 (0.09-1.71) | OI stratum | Mean: 23.8 SD: 24.4
Van Meurs, 2005^12^ | 36 weeks PMA | Control | 127 | 86 (68) | P-value: 0.26 | RR: 0.90 (0.75–1.08)
Van Meurs, 2005^12^ | 36 weeks PMA | iNO | 109 | 65 (60) | P-value: 0.26 | RR: 0.90 (0.75–1.08)
Ballard, 2006^1^ | 40 weeks PMA | Control | 288 | 84 (29.2)
Ballard, 2006^1^ | 40 weeks PMA | iNO | 294 | 66 (22.4)
Ballard, 2006^1^ | 44 weeks PMA | Control | 288 | 35 (12.2)
Ballard, 2006^1^ | 44 weeks PMA | iNO | 294 | 27 (9.2)
Dani, 2006^2^ | Duration of supplemental oxygen | Control | 20 | 69.4 days^*^
Dani, 2006^2^ | Duration of supplemental oxygen | iNO | 20 | 47.3 days^*^
Dani, 2006^2^ | Duration of supplemental oxygen | Nonresponders | 6 | 19.8 days^*^
Dani, 2006^2^ | Duration of supplemental oxygen | Responders | 14 | 48.6 days^*^
Field, 2005^3^ | 1 year corrected age | Control | 18 survivors | 1 (6)
Field, 2005^3^ | 1 year corrected age | iNO | 20 survivors | 3 (15)
Field, 2005^3^ | At term (EDC) | Control | 53 | 12 (23) | | | | Median: 81 IQR:14-100
Field, 2005^3^ | At term (EDC) | iNO | 55 | 16 (29) | | | | Median: 59 IQR:30-78
Franco-Belgium Collaborative NO Trial Group, 1999^4^ | 28 days | Control | 29 | 14 (48) | p-value: NS
Franco-Belgium Collaborative NO Trial Group, 1999^4^ | 28 days | iNO | 29 | 13 (45)
Kinsella, 1999^6^ | Hospital discharge | Control | 15 | 12 (80) | p-value: 0. 1
Kinsella, 1999^6^ | Hospital discharge | Control | 15 | 12 (80) | RR: 0.65 (0.41-1.02)
Kinsella, 1999^6^ | Hospital discharge | iNO | 25 | 13 (54) | p-value: 0.1 1.02)
Kinsella, 1999^6^ | Hospital discharge | iNO | 25 | 13 (54) | RR: 0.65(0.41-
Kinsella, 2006^5^ | Post-natal corticosteroids | Control | 365 | 204 (56) | p-value: 0.24
Kinsella, 2006^5^ | Post-natal corticosteroids | iNO | 369 | 222 (60) | p-value: 0.24
Schreiber, 2003^8^ | Duration of Mechanical Ventilation | Control | 102 | 28.5 days^*^
Schreiber, 2003^8^ | Duration of Mechanical Ventilation | iNO | 105 | 16 days
Su, 2008^9^ | Duration of Mechanical Ventilation | Control | 33 | 14.2 days^*^
Su, 2008^9^ | Duration of Mechanical Ventilation | iNO | 32 | 12.8 days *
Van Meurs, 2005^12^ | Days on Mechanical Ventilation | Control | 210 | 47 days^*^
Van Meurs, 2005^12^ | Days on Mechanical Ventilation | iNO | 210 | 39 days^*^
Van Meurs, 2007^11^ | Physiologic BPD as per Walsh criteria | Control | 10 | 4 (40) | p-value: 1 RR: 0.91 (0.31-2.70) | p-value: 0.61 RR: 0.74 (0.26-2.09)
Van Meurs, 2007^11^ | Physiologic BPD as per Walsh criteria | iNO | 11 | 4 (36) | p-value: 1 RR: 0.91 (0.31-2.70) | p-value: 0.61 RR: 0.74 (0.26-2.09)
Ballard, 2006^1^ | 40 weeks PMA, severe | Control | 288 | 30 (10.4)
Ballard, 2006^1^ | 40 weeks PMA, severe | iNO | 294 | 18 (6.1)
Ballard, 2006^1^ | 44 weeks PMA, severe | Control | 288 | 12 (4.2)
Ballard, 2006^1^ | 44 weeks PMA, severe | iNO | 294 | 6 (2)
Dani, 2006^2^ | In NICU, severe | Control | 20 | 20 (100) | | | | 14.9 (Mean) 18.1 (SD)
Dani, 2006^2^ | In NICU, severe | iNO | 20 | 20 (100) | 1 | | | 12.5 (Mean) 10.1 (SD) | 0.608
Dani, 2006^2^ | In NICU, severe | Nonresponders | 6 | 6 (100) | | | | 19 (Mean) 12.7 (SD)
Dani, 2006^2^ | In NICU, severe | Responders | 14 | 14 (100) | 1 | | | 15.8 (Mean) 17.3 (SD) | 0.69
Field, 2005^3^ | During hospitalization, severe | Control | 53 | | | | | 4 (Mean) 1.0-9.0 IQR
Field, 2005^3^ | During hospitalization, severe | iNO | 55 | | | | | 7 (Median) 2-26 IQR
Hascoet , 2005^13^ | 48 hours of life, severe | Control with HRF | 84 | 30 (35.7) | 0.024
Hascoet , 2005^13^ | 48 hours of life, severe | iNO with HRF | 61 | 49 (80.3) | 0.024
Franco-Belgium, 1999^4^ | during hospitalizati on, severe | Control | 29 | | | | | 16 (Median) 14 IQR | ns
Franco-Belgium, 1999^4^ | during hospitalizati on, severe | iNO | 29 | | | | | 12 (Median) 32 IQR | 0.78
Schreiber, 2003^8^ | Before Discharge, severe | Control | 79 survivors | | | | | 28.5 (Median) IQR 8-48
Schreiber, 2003^8^ | Before Discharge, severe | iNO | 89 survivors | | | | | 16 (Median) IQR 8-37 | 0.19
Subhedar, 1997^10^ | Before Discharge, severe | Dexamethas one and standard of care | 22 | | | | | 19 (Median) 5-39 range
Subhedar, 1997^10^ | Before Discharge, severe | Groups 1&3; iNO + iNO and dexamethas one | 20 | | | | | 11 (Median) 5-44 range
Subhedar, 1997^10^ | Before Discharge, severe | Dexamethas one alone AND dex + iNO | 21 | | | | | 23 (Median) 6-44 range
Subhedar, 1997^10^ | Before Discharge, severe | iNO AND standard of care | 21 | | | | | 13 (Median) 5-39 range
Subhedar, 1997^10^ | Time to extubation, severe | Dexamethas one and standard of care | 22 | | | | | 11 (Median) range 5-35
Subhedar, 1997^10^ | Time to extubation, severe | Groups 1&3; iNO + iNO and dexamethas one | 20 | | | | | 6.5 (Median) range 5-28
Subhedar, 1997^10^ | Time to extubation, severe | Dexamethas one alone AND dex + iNO | 21 | | | | | 8.5 (Median) 5-35 range
Subhedar, 1997^10^ | Time to extubation, severe | iNO AND standard of care | 21 | | | | | 11 (Median) 5-28 range
Van Meurs, 2005^12^ | NICU, severe | Control | 117 | | | | | Mean:47 SD: 53
Van Meurs, 2005^12^ | NICU, severe | iNO | 101 | | | | | Mean:39 SD:45 | 0.56

* Measure given in days, not number of participants

BPD: Bronchopulmonary Dysplasia, EDC: Estimated date of confinement, HFOV: High-frequency oscillatory ventilation, HRF: Hypoxemic respiratory failure, iNO: Inhaled Nitric Oxide, IQR: Inter-quartile range, NICU: Neonatal Intensive Care Unit, NS: Not significant, PMA: Post-menstrual age, SD: Standard Deviation

Evidence Table 7 Death of BPD outcomes for KQ1

Author, Year | Time of outcome measure | Arm Description | N (Number of Participants Measured) | Participants with Outcome n (%) | Relative Effect (95% CI) | Adjusted Relative Effect (95% CI) | Adjustments
Author, Year | Time of outcome measure | Arm Description | N (Number of Participants Measured) | Participants with Outcome n (%) | OR (95% CI) | Adjusted OR (95% CI) | Adjustments
Ballard, 2006^1^ | 36 weeks PMA | Control | 288 | 182 (63.2)
Ballard, 2006^1^ | 36 weeks PMA | iNO | 294 | 165 (56.1)
Dani, 2006^2^ | NICU | Control | 20 | 18 (90) | P-value: 0.016 OR: 0.111 (0.02-0.610)
Dani, 2006^2^ | NICU | iNO | 20 | 10 (50)
Dani, 2006^2^ | NICU | Nonresponders | 6 | 6 (100) | P-value: 0.035
Dani, 2006^2^ | NICU | Responders | 14 | 10 (71)
Field, 2005^3^ | 36 weeks PMA | Control | 53 | 48 (91)
Field, 2005^3^ | 36 weeks PMA | iNO | 55 | 49 (89)
Franco-Belgium Collaborative NO Trial Group, 1999^4^ | In NICU | Control | 45 | 24 (53)
Franco-Belgium Collaborative NO Trial Group, 1999^4^ | In NICU | iNO | 40 | 18 (45)
Kinsella, 1999^5^ | Discharge | Control | 32 | 29 (91) | P-value: 0.14 RR: 0.85(0.7-1.03)
Kinsella, 1999^5^ | Discharge | iNO | 48 | 37 (77) | P-value: 0.14 RR: 0.85(0.7-1.03)
Kinsella, 2006^6^ | 36 wks PMA | Control | 392 | 295 (75.3) | | P-value: 0.24 RR: 0.95 (0.87-1.03) | Study sight, randomization strata
Kinsella, 2006^6^ | 36 wks PMA | iNO | 394 | 282 (71.6)
Mercier, 2010^7^ | 24-28 weeks | Control | 400 | 138 (35)
Mercier, 2010^7^ | 24-28 weeks | iNO | 395 | 137 (35)
Schreiber, 2003^8^ | NICU | Control | 102 | 65 (63.7) | P-value: 0.03 RR: 0.76 (0.60-0.97) | RR: 0.77 (0.60-0.98) | type of ventilation
Schreiber, 2003^8^ | NICU | iNO | 105 | 51 (48.6)
Su, 2008^9^ | 36 weeks PMA | Control | 33 | 21 (64)
Su, 2008^9^ | 36 weeks PMA | iNO | 32 | 16 (50)
Subhedar, 1997^10^ | Before Discharge | Control | 22 | 21 (95) | RR = 1.05 (0.84-1.25)
Subhedar, 1997^10^ | Before Discharge | iNO | 20 | 20 (100) | RR = 1.05 (0.84-1.25)
Van Meurs, 2007^11^ | Death before discharge to home or within 365 | Control | 15 | 9 (60) | P-value: 0.87 RR: 0.83 (0.43-1.62) | p-value: 0.5 RR: 0.80 (0.43-1.48) | OI Stratum
Van Meurs, 2007^11^ | Death before discharge to home or within 365 | iNO | 14 | 7 (50) | P-value: 0.87 RR: 0.83 (0.43-1.62) | p-value: 0.5 RR: 0.80 (0.43-1.48) | OI Stratum
Van Meurs, 2005^12^ | before discharge to home or within 365 days among hospitalized infants | Control | 208 | 170 (82) | | P-value: 0.52 RR: 0.97 (0.86-1.06) | Birth weight, study site, Oxygenation index
Van Meurs, 2005^12^ | before discharge to home or within 365 days among hospitalized infants | iNO | 210 | 167 (80)

BPD: Bronchopulmonary Dysplasia, iNO: Inhaled nitric oxide, NICU: Neonatal intensive care unit, OI: Oxygenation Index, OR: Odds ratio, PMA: Post-menstrual age , RR: Relative risk

Evidence Table 8 Brain injury outcomes for KQ2

Author, Year | Outcomes | Time of outcome measure | Arm Description | N (number of participants measured) | Participants with outcome—n (%) | Relative Effect (95% CI) | Adjusted Relative Effect (95% CI) | Adjustments
Dani, 2006^1^ | Brain injury, any IVH | before discharge | Control | 20 | 4 (20) | P-value:0.725
Dani, 2006^1^ | Brain injury, any IVH | before discharge | iNO | 20 | 5 (25) | P-value:0.725
Hascoet, 2005^2^ | Brain injury, any IVH | 28 days | Control | 84 | 6 (7) | P-value: NS
Hascoet, 2005^2^ | Brain injury, any IVH | 28 days | iNO | 61 | 4 (6) | P-value: NS
Kinsella, 1999^3^ | Brain injury, any IVH | 7 days or 36 weeks postconception al age | iNO | 32 | 18 (56) | P-value: NS
Kinsella, 1999^3^ | Brain injury, any IVH | 7 days or 36 weeks postconception al age | Control | 17 | 10 (59) | P-value: NS
Su, 2008^4^ | Brain injury, any IVH | Not specified | Control | 33 | 12 (36.3)
Su, 2008^4^ | Brain injury, any IVH | Not specified | iNO | 32 | 8 (25)
Dani, 2006^1^ | Brain injury, IVH grades 3 and 4 | Before discharge | Control | 20 | 2 (10) | P-value: 1
Dani, 2006^1^ | Brain injury, IVH grades 3 and 4 | Before discharge | iNO | 20 | 2 (10) | P-value: 1
Dani, 2006^1^ | Brain injury, IVH grades 3 and 4 | Before discharge | Nonresponders | 6 | 3 (50) | P-value: 0.225
Dani, 2006^1^ | Brain injury, IVH grades 3 and 4 | Before discharge | Responders | 14 | 3 (21) | P-value: 0.225
Kinsella, 1999^3^ | Brain injury, IVH grades 3 and 4 | 7 days | Control | 43 | 16 (37)
Kinsella, 1999^3^ | Brain injury, IVH grades 3 and 4 | 7 days | iNO | 26 | 10 (40)
Kinsella, 2006^5^ | Brain injury, IVH grades 3 and 4 | 7 to 14 days of age and / or at more than 30 days of age | Control | 394 | 63 (16) | | p-value 0.14 RR: 0.77 (0.54-1.09) | study sight, randomization strata
Kinsella, 2006^5^ | Brain injury, IVH grades 3 and 4 | 7 to 14 days of age and / or at more than 30 days of age | iNO | 398 | 49 (12.3) | | | study sight, randomization strata
Mercier, 2010^6^ | Brain injury, IVH grades 3 and 4 | 24-28 weeks | Control | 397 | 32 (8)
Mercier, 2010^6^ | Brain injury, IVH grades 3 and 4 | 24-28 weeks | iNO | 395 | 24 (6.1)
Srisuparp, 2002^7^ | Brain injury, IVH grades 3 and 4 | 72 hours | Control | 18 | 5 (27.8)
Srisuparp, 2002^7^ | Brain injury, IVH grades 3 and 4 | 72 hours | iNO | 16 | 4 (25.1)
Su, 2008^4^ | Brain injury, IVH grades 3 and 4 | Not specified | Control | 33 | 8 (24.2)
Su, 2008^4^ | Brain injury, IVH grades 3 and 4 | Not specified | iNO | 32 | 4 (12.5)
Ballard, 2006^8^ | Brain Injury, IVH Grades 3 or 4 and / or PVL | after study entry | Control | 288 | 10 (4.1) | P-value: 0.67 RR:1.21(0.53-2.76)
Ballard, 2006^8^ | Brain Injury, IVH Grades 3 or 4 and / or PVL | after study entry | iNO | 294 | 13 (5) | P-value: 0.67 RR:1.21(0.53-2.76)
Franco-Belgium Collaborativ e NO Trial Group, 1999^9^ | Brain Injury, IVH Grades 3 or 4 and / or PVL | during hospitalization | Control | 45 | 12 (27) | P-value: NS
Franco-Belgium Collaborativ e NO Trial Group, 1999^9^ | Brain Injury, IVH Grades 3 or 4 and / or PVL | during hospitalization | iNO | 40 | 13 (32) | P-value: NS
Kinsella, 2006^5^ | Brain Injury, IVH Grades 3 or 4 and / or PVL | 21 days until extubation | Control | 364 | 87 (24)
Kinsella, 2006^5^ | Brain Injury, IVH Grades 3 or 4 and / or PVL | 21 days until extubation | iNO | 366 | 64 (17)
Schreiber, 2003^10^ | Brain Injury, IVH Grades 3 or 4 and / or PVL | NICU | Control | 102 | 24 (23.5) | P-value: 0.04 RR: 0.53 (0.28-0.98)
Schreiber, 2003^10^ | Brain Injury, IVH Grades 3 or 4 and / or PVL | NICU | iNO | 105 | 13 (12.4) | P-value: 0.04 RR: 0.53 (0.28-0.98)
Van Meurs, 2007^11^ | Brain Injury, IVH Grades 3 or 4 and / or PVL | 28 +/- 3 days | Control | 9 (HUS available) | 2 (22) | P-value: 0.47
Van Meurs, 2007^11^ | Brain Injury, IVH Grades 3 or 4 and / or PVL | 28 +/- 3 days | iNO | 9 | 0 (0) | P-value: 0.47
Van Meurs, 2005^12^ | Brain Injury, IVH Grades 3 or 4 and / or PVL | Not specified | Control | 155 | 50 (32) | P-value: 0. 11 RR: 1.25 (0.95-1.66)
Van Meurs, 2005^12^ | Brain Injury, IVH Grades 3 or 4 and / or PVL | Not specified | iNO | 170 | 69 (39) | P-value: 0. 11 RR: 1.25 (0.95-1.66)
Dani, 2006^1^ | Brain Injury, PVL | Before discharge | Control | 20 | 1 (5) | P-value: 0.5
Dani, 2006^1^ | Brain Injury, PVL | Before discharge | iNO | 20 | 0 (0) | P-value: 0.5
Dani, 2006^1^ | Brain Injury, PVL | Before discharge | Nonresponders | 6 | 0 (0) | P-value: 1
Dani, 2006^1^ | Brain Injury, PVL | Before discharge | Responders | 14 | 0 (0) | P-value: 1
Kinsella, 2006^5^ | Brain Injury, PVL | 7 to 14 days of age and / or at more than 30 days of age | Control | 356 | 32 (9) | | P-value: 0.048 RR: 0.58 (0.33-1.00) | study site, randomization strata
Kinsella, 2006^5^ | Brain Injury, PVL | 7 to 14 days of age and / or at more than 30 days of age | iNO | 365 | 19 (5.2) | | P-value: 0.048 RR: 0.58 (0.33-1.00) | study site, randomization strata
Kinsella, 1999^3^ | Brain Injury, PVL | 7 days or 36 weeks postconception al age | Control | 15 | 2 (13) | P-value: 0.62
Kinsella, 1999^3^ | Brain Injury, PVL | 7 days or 36 weeks postconception al age | iNO | 25 | 2 (8) | P-value: 0.62
Mercier, 2010^6^ | Brain Injury, PVL | 24-28 weeks | Control | 397 | 1 (0.2)
Mercier, 2010^6^ | Brain Injury, PVL | 24-28 weeks | iNO | 395 | 7 (1.7)
Su, 2008^4^ | Brain Injury, PVL | Not specified | Control | 33 | 4 (12.1)
Su, 2008^4^ | Brain Injury, PVL | Not specified | iNO | 32 | 3 (9.4)

CI: Confidence Interval, iNO: Inhaled nitric oxide, IVH: Intraventricular hemorrhage, NS: Not significant, PVL: Periventricular leukomalacia, RR: Relative risk

Evidence Table 9 Other short term outcomes addressing KQ2 including PDA, sepsis, NEC, ROP, Pulmonary outcomes, and methemoglobinemia

Author, Year | Outcomes | Time of outcome measure | Arm Description | N (number of participants measured) | Participants with outcome—n (%) | Relative Effect (95% CI) | Adjusted Relative Effect (95% CI) | Adjustments
Ballard, 2006^1^ | Cardiac Outcomes, PDA Requiring Medical or Surgical Treatment | after study entry | Control | 288 | 55 (19.1) | P-value: 0.85 RR: 0.96 (0.68-1.35)
Ballard, 2006^1^ | Cardiac Outcomes, PDA Requiring Medical or Surgical Treatment | after study entry | iNO | 294 | 54 (18.4) | P-value: 0.85 RR: 0.96 (0.68-1.35)
Field, 2005^2^ | Cardiac Outcomes, PDA Requiring Medical or Surgical Treatment | during hospitalization | Control | 53 | 13 (25)
Field, 2005^2^ | Cardiac Outcomes, PDA Requiring Medical or Surgical Treatment | during hospitalization | iNO | 55 | 9 (16)
Schreiber, 2003^3^ | Cardiac Outcomes, PDA Requiring Medical or Surgical Treatment | Before discharge | Control | 102 | 26 (25.5) | P-value: 0.27 RR: 0.75 (0.45-1.25)
Schreiber, 2003^3^ | Cardiac Outcomes, PDA Requiring Medical or Surgical Treatment | Before discharge | iNO | 105 | 20 (19) | P-value: 0.27 RR: 0.75 (0.45-1.25)
Kinsella, 2006^4^ | Cardiac Outcomes, PDA Requiring Medical Treatment | Before discharge | Control | 395 | 212 (53.7) | | P-value: 0.92 | study sight, randomization strata
Kinsella, 2006^4^ | Cardiac Outcomes, PDA Requiring Medical Treatment | Before discharge | iNO | 398 | 215 (54) | | P-value: 0.92 | study sight, randomization strata
Srisuparp, 2002^5^ | Cardiac Outcomes, PDA Requiring Medical Treatment | Before discharge | Control | 18 | 1 (5.6) | P-value: 1
Srisuparp, 2002^5^ | Cardiac Outcomes, PDA Requiring Medical Treatment | Before discharge | iNO | 16 | 0 (0) | P-value: 1
Su, 2008^6^ | Cardiac Outcomes, PDA Requiring Medical Treatment | Before discharge | Control | 33 | 8 (24.2)
Su, 2008^6^ | Cardiac Outcomes, PDA Requiring Medical Treatment | Before discharge | iNO | 32 | 9 (28.1)
Subhedar, 1997^7^ | Cardiac Outcomes, PDA Requiring Medical Treatment | Before discharge | Control dexamethasone and standard of care | 22 | 1 (5)
Subhedar, 1997^7^ | Cardiac Outcomes, PDA Requiring Medical Treatment | Before discharge | Groups 1&3; iNO + iNO and dexamethasone | 20 | 3 (15)
Subhedar, 1997^7^ | Cardiac Outcomes, PDA Requiring Medical Treatment | Before discharge | Dexamethasone alone AND dex + iNO | 21 | 1 (5)
Subhedar, 1997^7^ | Cardiac Outcomes, PDA Requiring Medical Treatment | Before discharge | iNO AND standard of care | 21 | 2 (10)
Kinsella, 2006^4^ | Cardiac Outcomes, PDA requiring surgical treatment | Before discharge | Control | 395 | 86 (21.8) | | P-value: 0.96 | study sight, randomization strata
Kinsella, 2006^4^ | Cardiac Outcomes, PDA requiring surgical treatment | Before discharge | iNO | 398 | 86 (21.6) | | P-value: 0.96 | study sight, randomization strata
Mercier, 2010^8^ | Cardiac Outcomes, PDA requiring surgical treatment | 24-28 weeks | Control | 397 | 45 (11.3)
Mercier, 2010^8^ | Cardiac Outcomes, PDA requiring surgical treatment | 24-28 weeks | iNO | 395 | 59 (14.9)
Srisuparp, 2002^5^ | Cardiac Outcomes, PDA requiring surgical treatment | Before discharge | Control | 18 | 0 (0) | P-value: 0.47
Srisuparp, 2002^5^ | Cardiac Outcomes, PDA requiring surgical treatment | Before discharge | iNO | 16 | 1 (6.3) | P-value: 0.47
Subhedar, 1997^7^ | Cardiac Outcomes, PDA requiring surgical treatment | Before discharge | Control dexamethasone and standard of care | 22 | 2 (10)
Subhedar, 1997^7^ | Cardiac Outcomes, PDA requiring surgical treatment | Before discharge | Groups 1&3; iNO + iNO and dexamethasone | 20 | 1 (5)
Subhedar, 1997^7^ | Cardiac Outcomes, PDA requiring surgical treatment | Before discharge | Dexamethasone alone AND dex + iNO | 21 | 2 (10)
Subhedar, 1997^7^ | Cardiac Outcomes, PDA requiring surgical treatment | Before discharge | iNO AND standard of care | 21 | 2 (10)
Dani, 2006^9^ | Cardiac Outcomes, Incidence of PDA | Before discharge | Control | 20 | 18 (90) | P-value: 0.421
Dani, 2006^9^ | Cardiac Outcomes, Incidence of PDA | Before discharge | iNO | 20 | 16 (80) | P-value: 0.421
Dani, 2006^9^ | Cardiac Outcomes, Incidence of PDA | Before discharge | Nonresponders | 6 | 5 (60) | P-value: 0.657
Dani, 2006^9^ | Cardiac Outcomes, Incidence of PDA | Before discharge | Responders | 14 | 11 (80) | P-value: 0.657
Kinsella, 1999^10^ | Cardiac Outcomes, Symptomatic PDA | Before discharge | Control | Unclear | Unclear (19) | P-value: NS
Kinsella, 1999^10^ | Cardiac Outcomes, Symptomatic PDA | Before discharge | iNO | Unclear | Unclear (21) | P-value: NS
Subhedar, 1997^7^ | Cardiac Outcomes, Symptomatic PDA | Before discharge | Control dexamethasone and standard of care | 22 | 3 (15)
Subhedar, 1997^7^ | Cardiac Outcomes, Symptomatic PDA | Before discharge | Groups 1&3; iNO + iNO and dexamethasone | 20 | 4 (20)
Subhedar, 1997^7^ | Cardiac Outcomes, Symptomatic PDA | Before discharge | Dexamethasone alone AND dex + iNO | 21 | 3 (14)
Subhedar, 1997^7^ | Cardiac Outcomes, Symptomatic PDA | Before discharge | iNO AND standard of care | 21 | 4 (19)
Hascoet, 2005^11^ | Cardiac Outcomes, Undefined PDA | 28 days | Control with Hypoxemic Respiratory Failure | 84 | 31 (37) | P-value: NS
Hascoet, 2005^11^ | Cardiac Outcomes, Undefined PDA | 28 days | iNO with Hypoxemic Respiratory Failure | 61 | 20.74 (34) | P-value: NS
Dani, 2006^9^ | Sepsis Defined by Positive Culture | before discharge | Control | 20 | 10 (50)
Dani, 2006^9^ | Sepsis Defined by Positive Culture | before discharge | iNO | 20 | 8 (40) | 0.751
Dani, 2006^9^ | Sepsis Defined by Positive Culture | before discharge | Responders | 6 | 2 (33)
Dani, 2006^9^ | Sepsis Defined by Positive Culture | before discharge | Nonresponders | 14 | 6 (43) | 0.545
Field, 2005^2^ | Sepsis Defined by Positive Culture | during hospitalization | Control | 53 | 21 (40)
Field, 2005^2^ | Sepsis Defined by Positive Culture | during hospitalization | iNO | 55 | 23 (42)
Srisuparp, 2002^5^ | Sepsis Defined by Positive Culture | Unspecified | Control | 18 | 7 (38.9) | 1
Srisuparp, 2002^5^ | Sepsis Defined by Positive Culture | Unspecified | iNO | 16 | 7 (43.8) | 1
Field, 2005^2^ | Sepsis Defined by Clinician | during hospitalization | Control | 53
Field, 2005^2^ | Sepsis Defined by Clinician | during hospitalization | iNO | 55 | 12 (22)
Su, 2008 {#200) | Undefined Sepsis | Unspecified | Control | 33 | 2 (6.1)
Su, 2008 {#200) | Undefined Sepsis | Unspecified | iNO | 32 | 3 (9.4)
Kinsella, 2006^4^ | Undefined Sepsis | Unspecified | Control | 369 | 118 (32)
Kinsella, 2006^4^ | Undefined Sepsis | Unspecified | iNO | 381 | 139 (0.365) | | 0.19 | randomization strata, study sight
Ballard, 2006^1^ | Undefined Sepsis | after study entry | Control | 288 | 118 (41) | 0.91
Ballard, 2006^1^ | Undefined Sepsis | after study entry | Control | 288 | 118 (41) | 0.98(0.80-1.20)
Ballard, 2006^1^ | Undefined Sepsis | after study entry | iNO | 294 | 121 (41.2) | 0.91
Ballard, 2006^1^ | Undefined Sepsis | after study entry | iNO | 294 | 121 (41.2) | 0.98(0.80-1.20)
Schreiber, 2003^3^ | Undefined Sepsis | After 24 hours of age | Control | 102 | 50 (49)
Schreiber, 2003^3^ | Undefined Sepsis | After 24 hours of age | iNO | 105 | 54 (51.5) | 0.73
Schreiber, 2003^3^ | Undefined Sepsis | After 24 hours of age | iNO | 105 | 54 (51.5) | 1.05 (0.80-1.38)
Ballard, 2006^1^ | Cardiac Outcomes, NEC requiring surgical treatment | after study entry | Control | 288 | 19 (6.6) | P-value: 0.63 RR: 1.17(0.64-2.13)
Ballard, 2006^1^ | Cardiac Outcomes, NEC requiring surgical treatment | after study entry | iNO | 294 | 23 (7.8) | P-value: 0.63 RR: 1.17(0.64-2.13)
Ballard, 2006^1^ | Cardiac Outcomes, NEC requiring medical treatment | after study entry | Control | 288 | 8 (2.8) | P-value: 0.84 RR:1.20(0.46-3.13)
Ballard, 2006^1^ | Cardiac Outcomes, NEC requiring medical treatment | after study entry | iNO | 294 | 10 (3.4) | P-value: 0.84 RR:1.20(0.46-3.13)
Dani, 2006^9^ | Cardiac Outcomes, NEC diagnosed by clinical criteria | Before discharge | Control | 20 | 0 (0) | P-value: 0.5
Dani, 2006^9^ | Cardiac Outcomes, NEC diagnosed by clinical criteria | Before discharge | iNO | 20 | 1 (5) | P-value: 0.5
Dani, 2006^9^ | Cardiac Outcomes, NEC diagnosed by clinical criteria | Before discharge | Nonresponders | 6 | 0 (0) | P-value: 0.7
Dani, 2006^9^ | Cardiac Outcomes, NEC diagnosed by clinical criteria | Before discharge | Responders | 14 | 1 (7) | P-value: 0.7
Hascoet, 2005^11^ | Cardiac Outcomes, NEC undefined | 28 days of life | Control with Hypoxemic Respiratory Failure | 84 | (6) | NS
Hascoet, 2005^11^ | Cardiac Outcomes, NEC undefined | 28 days of life | iNO with Hypoxemic Respiratory Failure | 61 | (8) | NS
Kinsella, 2006^4^ | Cardiac Outcomes, NEC undefined | Before discharge | Control | 369 | 46 (12.5) | | 0.54 | study site, randomization strata
Kinsella, 2006^4^ | Cardiac Outcomes, NEC undefined | Before discharge | iNO | 379 | 53 (14) | | 0.54
Mercier, 2010^8^ | Cardiac Outcomes, NEC undefined | Before discharge | Control | 397 | 7 (1.8)
Mercier, 2010^8^ | Cardiac Outcomes, NEC undefined | Before discharge | iNO | 395 | 11 (2.8)
Schreiber, 2003^3^ | Cardiac Outcomes, NEC undefined | before discharge | Control | 102 | 6 (5.9) | P-value: 0.11 RR: 2.10 (0.83-5.32)
Schreiber, 2003^3^ | Cardiac Outcomes, NEC undefined | before discharge | iNO | 105 | 13 (12.4) | P-value: 0.11 RR: 2.10 (0.83-5.32)
Su, 2008^6^ | Cardiac Outcomes, NEC undefined | Before discharge | Control | 33 | 2 (6.1)
Su, 2008^6^ | Cardiac Outcomes, NEC undefined | Before discharge | iNO | 32 | 2 (6.3)
Subhedar, 1997^7^ | Cardiac Outcomes, NEC undefined | before discharge | Control dexamethasone and standard of care | 22 | 2 (10)
Subhedar, 1997^7^ | Cardiac Outcomes, NEC undefined | before discharge | Groups 1&3; iNO + iNO and dexamethasone | 20 | 1 (5)
Subhedar, 1997^7^ | Cardiac Outcomes, NEC undefined | before discharge | Dexamethasone alone AND dex + iNO | 21 | 2 (10)
Subhedar, 1997^7^ | Cardiac Outcomes, NEC undefined | before discharge | iNO AND standard of care | 21 | 1 (5)
Ballard, 2006^1^ | ROP requiring treatment by cryo or laser | After study entry | Control | 288 | 68 (23.6) | p-value: 0.95 RR = 0.97 (0.72-1.31)
Ballard, 2006^1^ | ROP requiring treatment by cryo or laser | After study entry | iNO | 294 | 72 (24.5) | p-value: 0.95 RR = 0.97 (0.72-1.31)
Field, 2005^2^ | ROP requiring treatment by cryo or laser | Before hospital discharge | Control | 49 | 4 (8)
Field, 2005^2^ | ROP requiring treatment by cryo or laser | Before hospital discharge | iNO | 50 | 8 (16)
Kinsella, 1999^10^ | ROP requiring treatment by cryo or laser | Before hospital discharge | Control | 15 | 3 (20) | P-value: 0.1
Kinsella, 1999^10^ | ROP requiring treatment by cryo or laser | Before hospital discharge | iNO | 25 | 1 (4) | P-value: 0.1
Kinsella, 2006^4^ | ROP requiring treatment by cryo or laser | Before Discharge | Control | 395 | 60 (15.2) | P-value: 0.59
Kinsella, 2006^4^ | ROP requiring treatment by cryo or laser | Before Discharge | iNO | 398 | 66 (16.6) | P-value: 0.59
Schreiber, 2003^3^ | ROP requiring treatment by cryo or laser | Before hospital discharge | Control | 102 | 10 (9.8) | P-value: 0.27
Schreiber, 2003^3^ | ROP requiring treatment by cryo or laser | Before hospital discharge | iNO | 105 | 6 (5.7) | P-value: 0.27
Subhedar, 1997^7^ | ROP requiring treatment by cryo or laser | Before Hospital Discharge | Control dexamethasone and standard of care | 22 | 0 (0)
Subhedar, 1997^7^ | ROP requiring treatment by cryo or laser | Before Hospital Discharge | Groups 1&3; iNO + iNO and dexamethasone | 20 | 2 (10)
Subhedar, 1997^7^ | ROP requiring treatment by cryo or laser | Before Hospital Discharge | Dexamethasone alone AND dex + iNO | 21 | 2 (10)
Subhedar, 1997^7^ | ROP requiring treatment by cryo or laser | Before Hospital Discharge | iNO AND standard of care | 21 | 0 (0)
Van Meurs, 2007^12^ | ROP requiring treatment by cryo or laser | Before Discharge | Control | 5 | 2 (40) | P-value: 0.44
Van Meurs, 2007^12^ | ROP requiring treatment by cryo or laser | Before Discharge | iNO | 5 | 0 (0) | P-value: 0.44
Van Meurs, 2005^13^ | ROP requiring treatment by cryo or laser | before hospital discharge | Control | 112 | 36 (32) | | P-value: 0.42 | Study center, Oxygenation index, birth weight
Van Meurs, 2005^13^ | ROP requiring treatment by cryo or laser | before hospital discharge | iNO | 98 | 29 (30) | | P-value: 0.42 | Study center, Oxygenation index, birth weight
Field, 2005^2^ | Pulmonary Hemorrhage | Hospital discharge | Control | 53 | 5 (9)
Field, 2005^2^ | Pulmonary Hemorrhage | Hospital discharge | iNO | 55 | 4 (7)
Kinsella, 2006^4^ | Pulmonary Hemorrhage | Before discharge | Control | 395 | 26 (6.6) | | 0.75 | study sight, randomization strata
Kinsella, 2006^4^ | Pulmonary Hemorrhage | Before discharge | iNO | 398 | 24 (6) | | 0.75
Mercier, 2010^8^ | Pulmonary Hemorrhage | Discharge | Control | 397 | 14 (3.5)
Mercier, 2010^8^ | Pulmonary Hemorrhage | Discharge | iNO | 395 | 12 (3)
Schreiber, 2003^3^ | Pulmonary Hemorrhage | Before discharge | Control | 102 | 4 (3.8) | P-value: 0.37 RR:0.56 (0.17-1.84)
Schreiber, 2003^3^ | Pulmonary Hemorrhage | Before discharge | iNO | 105 | 7 (6.9) | P-value: 0.37 RR:0.56 (0.17-1.84)
Su, 2008^6^ | Pulmonary Hemorrhage | Before discharge | Control | 33 | 2 (6.1)
Su, 2008^6^ | Pulmonary Hemorrhage | Before discharge | iNO | 32 | 3 (9.4)
Field, 2005^2^ | Air Leak | Hospital discharge | Control | 53 | 20 (38)
Field, 2005^2^ | Air Leak | Hospital discharge | iNO | 55 | 20 (36)
Kinsella, 1999^10^ | Air Leak
Kinsella, 1999^10^ | Air Leak
Kinsella, 2006^4^ | Air Leak | Before discharge | Control | 395 | 24 (6.1) | | P-value: 0.94 | study sight, randomization strata
Kinsella, 2006^4^ | Air Leak | Before discharge | iNO, Total sample) | 398 | 25 (6.3) | | P-value: 0.94 | study sight, randomization strata
Mercier, 2010^8^ | Air Leak | 24-28 weeks | Control | 397 | 13(3)
Mercier, 2010^8^ | Air Leak | 24-28 weeks | iNO | 395 | 12 (2)
Schreiber, 2003^3^ | Air Leak | Before discharge | Control | 102 | 16 (15.7) | P-value: 0.27 RR: 0.67 (0.33-1.37)
Schreiber, 2003^3^ | Air Leak | Before discharge | iNO | 105 | 11 (10.5) | P-value: 0.27 RR: 0.67 (0.33-1.37)
Schreiber, 2003^3^ | Air Leak | Before discharge | Control | 102 | Pulmonary interstitial emphysema 35 (34.3) | P-value: 0.23 RR: 0.78 (0.51-1.18)
Schreiber, 2003^3^ | Air Leak | Before discharge | iNO | 105 | Pulmonary interstitial emphysema 28 (26.7)
Srisuparp, 2002^5^ | Air Leak | 72 hours | Control | 18 | 1 (5.6) | p-value: 0.59
Srisuparp, 2002^5^ | Air Leak | 72 hours | iNO | 16 | 2 (12.5) | p-value: 0.59
Su, 2008^6^ | Air Leak | Before discharge | Control | 33 | 2 (6.1)
Su, 2008^6^ | Air Leak | Before discharge | iNO | 32 | 2 (6.3)
Subhedar, 1997^7^ | Air Leak | Before discharge | Control dexamethasone and standard of care | 22 | 1 (5)
Subhedar, 1997^7^ | Air Leak | Before discharge | Groups 1&3; iNO + iNO and dexamethasone | 20 | 3 (15)
Subhedar, 1997^7^ | Air Leak | Before discharge | Dexamethasone alone AND dex + iNO | 21 | 3 (14)
Subhedar, 1997^7^ | Air Leak | Before discharge | iNO AND standard of care | 21 | 1 (5)
Van Meurs, 2005^13^ | Air Leak | Before discharge | Control | 117 | 37 (32) | | P-value: 0.55 RR: 1.12 (0.78-1.61) | center, Oxygenation index, birth weight
Van Meurs, 2005^13^ | Air Leak | Before discharge | iNO | 101 | 35 (35) | | P-value: 0.55 RR: 1.12 (0.78-1.61) | center, Oxygenation index, birth weight
Van Meurs, 2007^12^ | Air Leak | discharge | Control | 11 | 2 (18) | P-value:0.48
Van Meurs, 2007^12^ | Air Leak | discharge | iNO | 9 | 0 (0) | P-value:0.48
Schreiber, 2003^3^ | Cardiac Outcomes, Methemoglobi nemia >4% | Before discharge | Control | 102 | 0 (0)
Schreiber, 2003^3^ | Cardiac Outcomes, Methemoglobi nemia >4% | Before discharge | iNO | 105 | 3 (2.9)
Van Meurs, 2007^12^ | Cardiac Outcomes, Methemoglobi nemia >4% | Before discharge | Control | 14 | 0 (0)
Van Meurs, 2007^12^ | Cardiac Outcomes, Methemoglobi nemia >4% | Before discharge | iNO | 14 | 0 (0)
Van Meurs, 2005^13^ | Cardiac Outcomes, Methemoglobi nemia >4% | Before discharge | Control | 210 | 2 (1) | | | center, Oxygenation index
Van Meurs, 2005^13^ | Cardiac Outcomes, Methemoglobi nemia >4% | Before discharge | iNO | 210 | 2 (1)
Schreiber, 2003^3^ | Cardiac Outcomes, Methemoglobi nemia >8% | Before discharge | Control | 102 | 0 (0)
Schreiber, 2003^3^ | Cardiac Outcomes, Methemoglobi nemia >8% | Before discharge | iNO | 105 | 0 (0)
Van Meurs, 2005^13^ | Cardiac Outcomes, Methemoglobi nemia >8% | Before discharge | Control | 210 | 0 (0) | | P-value: 0.99 | center, Oxygenation index

CI: Confidence Interval; HRF: Hypoxemic respiratory failure; iNO: Inhaled nitric oxide; NEC: Necrotizing enterocolitis; NS: Not significant,: Relative risk; PDA: Patent Ductus Arteriosis; ROP: Retinopathy of Prematurity; RR: Relative risk;

Evidence Table 10 Death and survival beyond the NICU for KQ3

Study, year | Outcomes | Time of outcome measure | Study Arm | N (Participant Measured) | Participants with Outcome—n (%) | Relative Effect (95% CI) | Adjusted. Relative Effect (95% CI) | Adjustments
Bennett, 2001^1^ | Death | 30 months corrected age | Control | 22 | 7 (32) | P-value: 0.13 RR: 1.65 (0.87–3.3)
Bennett, 2001^1^ | Death | 30 months corrected age | iNO | 20 | 10 (50) | P-value: 0.13 RR: 1.65 (0.87–3.3)
Hintz, 2007^2^ | Death | 18-22 months | Control | 98 | 210 (47)
Hintz, 2007^2^ | Death | 18-22 months | iNO | 109 | 210 (52)
Huddy, 2008^3^ | Death | 4-5 years, median 4.52 (IQR 0.9) | Control | 19 | 0 (0)
Huddy, 2008^3^ | Death | 4-5 years, median 4.63, IQR 0.84) | iNO | 25 | 1 (4)
Walsh, 2010^4^ | Death | 2 years | Control | 288 | 23 (8) | RR: 1.02 (0.59-1.77)
Walsh, 2010^4^ | Death | 2 years | iNO | 294 | 24 (8.2) | RR: 1.02 (0.59-1.77)
Watson, 2009^5^ | Death | 1 year corrected age | Control | 384 | 98 (25.5) | P-value: 0.12
Watson, 2009^5^ | Death | 1 year corrected age | iNO | 385 | 80 (20.8) | P-value: 0.12
Mestan KK, 2005^6^ | Survival | 25.2+/-8.4 months corrected age | Control | 102 | 79 (0.775)
Mestan KK, 2005^6^ | Survival | 24.9 +/-7.9 months corrected age | iNO | 105 | 89 (84.8)

CP: Cerebral palsy, iNO: Inhaled nitric oxide, IQR: Inter-quartile range, MDI: Mental developmental index, NDI: Neurodevelopmental impairment, NS: Not significant,OI: Oxygenation index, PDI: Physical developmental index

Evidence Table 11 Cerebral palsy outcomes in KQ3

Refid | Outcome | Time of Outcome Measure | Study Arm | N (Participants Measured) | Number of Participants with Outcome—n (%) | Relative Effect (95% CI) | Adjusted Relative Effect (95% CI) | Adjustments
Bennett, 2001^1^ | Moderate / Severe CP | 18 to 22 months | Control | 14 | 2 (14.3)
Bennett, 2001^1^ | Moderate / Severe CP | 18 to 22 months | iNO | 7 | 0 (0)
Hintz SR, 2007^2^ | Moderate / Severe CP | 3 years | Control | 102 | 11 (11) | P-value; 0.11 RR: 1.85 (0.93-3.71) | P-value: Model #1: 0.0453; Model #2: 0.048 RR: Model #1: 2.01 (1.01-3.98); Model #2 2.41 (1.01-5.75) | Model #1: adjusted for BWt, center, sex, and OI entry criterion, birth weight, Model #2: adjusted for BWt, center, OI entry criterion, sex, BPD, IVH gr 3 or 4 or PVL, length of iNO exposure, postnatal steroids
Hintz SR, 2007^2^ | Moderate / Severe CP | 3 years | iNO | 90 | 18 (20) | P-value; 0.11 RR: 1.85 (0.93-3.71) | P-value: Model #1: 0.0453; Model #2: 0.048 RR: Model #1: 2.01 (1.01-3.98); Model #2 2.41 (1.01-5.75)
Huddy, 2008^3^ | Mild CP | 4-5 years | iNO | 16 | 4 (25)
Huddy, 2008^3^ | Mild CP | 4-5 years | Control | 22 | 6 (27.3)
Huddy, 2008^3^ | Moderate / Severe CP | 4-5 years | Control | 16 | 2 (12.5)
Huddy, 2008^3^ | Moderate / Severe CP | 4-5 years | iNO | 22 | 3 (13.6)
Mestan KK, 2005^4^ | Any CP | 25.2+/-8.4 months corrected age 24.9+/-7.9 months corrected age | Control | 68 | 7 (10) | P-value: 0.78
Mestan KK, 2005^4^ | Any CP | 25.2+/-8.4 months corrected age 24.9+/-7.9 months corrected age | iNO | 70 | 6 (9) | P-value: 0.78
Tanaka, 2007^5^ | Any CP | 3 years | Control | 15 | 7 (46.7)
| | | iNO | 16 | 2 (12.5)
Van Meurs, 2007^6^ | Moderate/Severe CP | 18-22 months | Control | 0 | 8 (0)
| | | iNO | 0 | 9 (0)
Walsh, 2010^7^ | Moderate / Severe CP | 2 years | Control | 234 | 12 (5.1) | RR: 1.23 (0.59-2.55)
| | 24.9+/-7.9 months corrected age | iNO | 243 | 15 (6.2)

CI: Confidence Interval, CP: Cerebral Palsy, iNO: Inhaled Nitric Oxide, OI: Oxygenation Index, RR: Risk Ratio

Evidence Table 12 Cognitive outcomes for KQ3

Author, year | Outcome | Time of Outcome Measure | Study Arm | N (Participants Measured) | Number of Participants with Outcome—n (%) | Relative Effect (95% CI) | Adjusted Relative Effect (95% CI) | Adjustments
Hintz, 2007^1^ | NDI: any of the following: mod-severe CP, blind, deaf, MDI<70 or PDI<70 | 18-22 months | Control | 102 | 48 (47) | P-value:0.74 RR: 1.07 (0.80 - 1.44) | | Model #1: BW, center, OI entry criterion strata, sex, Model #2: same as model #1 + BPD, IVH gr 3 or 4 or PVL, length of iNO exposure, postnatal steroids
Hintz, 2007^1^ | NDI: any of the following: mod-severe CP, blind, deaf, MDI<70 or PDI<70 | 18-22 months | iNO | 89 | 45 (51)
Hintz, 2007^1^ | Isolated delay = MDI<70 or PDI<70 in absence of mod-severe CP, deafness or blindness | 18-22 months | Control | 102 | 35 (34) | P-value:0.37 RR:0.79 (0.51-1.23) | P-value: Model #1: 0.78: Model #2 0.37 RR: Model #1: 1.04 (0.79-1.36); Model #2: 1.19 (0.81-1.73) | Model #1: BW, center, OI entry criterion strata, sex
Hintz, 2007^1^ | Isolated delay = MDI<70 or PDI<70 in absence of mod-severe CP, deafness or blindness | 18-22 months | iNO | 88 | 24 (27)
Huddy, 2008^2^ | Any cognitive disability (GCAS<85) | 4-5 yrs, median 4.52 (IQR 0.9) | Control | 16 | 9 (56.2)
Huddy, 2008^2^ | Any cognitive disability (GCAS<85) | 4-5 yrs, median 4.63, IQR 0.84) | iNO | 22 | 11 (50)
Huddy, 2008^2^ | Moderate or severe cognitive disability (GCAS<70) | 4-5 yrs, median 4.52 (IQR 0.9) | Control | 16 | 6 (37.5)
Huddy, 2008^2^ | Moderate or severe cognitive disability (GCAS<70) | 4-5 yrs, median 4.63, IQR 0.84) | iNO | 22 | 6 (27.3)
Huddy, 2008^2^ | Severe cognitive disability (GCAS <50) | 4-5 yrs, median 4.52 (IQR 0.9) | Control | 16 | 3 (18.7)
Huddy, 2008^2^ | Severe cognitive disability (GCAS <50) | 4-5 yrs, median 4.63, IQR 0.84) | iNO | 22 | 3 (13.6)
Huddy, 2008^2^ | GCAS>84 | 4-5 yrs, median 4.52 (IQR 0.9) | Control | 16 | 7 (43.7)
Huddy, 2008^2^ | GCAS>84 | 4-5 yrs, median 4.63, IQR 0.84) | iNO | 22 | 11 (50)
Huddy, 2008^2^ | Overall outcome: severe disability | 4-5 yrs, median 4.52 (IQR 0.9) | Control | 16 | 3 (18.7)
Huddy, 2008^2^ | Overall outcome: severe disability | 4-5 yrs, median 4.63, IQR 0.84) | iNO | 22 | 3 (13.6)
Huddy, 2008^2^ | Overall outcome: Moderate disability | 4-5 yrs, median 4.52 (IQR 0.9) | Control | 16 | 4 (25)
Huddy, 2008^2^ | Overall outcome: Moderate disability | 4-5 yrs, median 4.63, IQR 0.84) | iNO | 22 | 5 (22.7)
Huddy, 2008^2^ | Overall outcome: Normal | 4-5 yrs, median 4.52 (IQR 0.9) | Control | 16 | 3 (18.7)
Huddy, 2008^2^ | Overall outcome: Normal | 4-5 yrs, median 4.63, IQR 0.84) | iNO | 22 | 5 (22.7)
Huddy, 2008^2^ | Overall outcome: mild disability | 4-5 yrs, median 4.52 (IQR 0.9) | Control | 16 | 4 (25)
Huddy, 2008^2^ | Overall outcome: mild disability | 4-5 yrs, median 4.63, IQR 0.84) | iNO | 22 | 6 (27.3)
Mestan, 2005^3^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 25.2+/- 8.4 months corrected age 24.9 +/- 7.9 months corrected age | Control | 67 | 31 (46) | P-value:0.01 RR: 0.53 (0.33-0.87) | P-value: Model #1: 0.50: Model #2: 0.79 RR: Model #1: 0.85 (0.54-1.35); Model #2: 0.91 (0.46-1.81)
Mestan, 2005^3^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 25.2+/- 8.4 months corrected age 24.9 +/- 7.9 months corrected age | iNO | 70 | 17 (24) | P-value:0.01 RR: 0.53 (0.33-0.87) | P-value: Model #1: 0.50: Model #2: 0.79 RR: Model #1: 0.85 (0.54-1.35); Model #2: 0.91 (0.46-1.81)
Mestan, 2005^3^ | Abnormal neurodevelopme ntal outcome (any disability or any BSID II score <70) | 25.2+/- 8.4 months corrected age | Control | 67 | | | | birth weight
Mestan, 2005^3^ | Abnormal neurodevelopme ntal outcome (any disability or any BSID II score <70) | 24.9 +/-7.9 months corrected age | iNO | 70 | | | | birth weight
Mestan, 2005^3^ | Abnormal neurodevelopme ntal outcome (any disability or any BSID II score <70) | 25.2+/-8.4 months corrected age | Control | 67 | | | P-value:0.002 RR:0.57(0.35-0.93 | sex
Mestan, 2005^3^ | Abnormal neurodevelopme ntal outcome (any disability or any BSID II score <70) | 24.9 +/-7.9 months corrected age | iNO | 70 | | | P-value:0.002 RR:0.57(0.35-0.93 | sex
Mestan, 2005^3^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 25.2+/-8.4 months corrected age | Control | 67 | | | P-value:0.006 RR:0.52 (0.32-0.82) | Mother graduation fromhigh school
Mestan, 2005^3^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 24.9 +/-7.9 months corrected age | iNO | 70 | | | P-value:0.006 RR:0.52 (0.32-0.82) | Mother graduation fromhigh school
Mestan, 2005^3^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 25.2+/-8.4 months corrected age | Control | 67 | | | P-value:0.007 RR:0.48 (0.28-0.82) | household without employed person
Mestan, 2005^3^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 24.9 +/-7.9months corrected age | iNO | 70 | | | P-value:0.007 RR:0.48 (0.28-0.82) | household without employed person
Mestan, 2005^3^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 25.2+/- 8.4 Months corrected age | Control | 67 | | | P-value:0.006 RR:0.49 (0.29-0.82) | type of ventilation
Mestan, 2005^3^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 24.9 +/-7.9 months corrected age | iNO | 70 | | | P-value:0.006 RR:0.49 (0.29-0.82) | type of ventilation
Mestan, 2005^3^ | Abnormal neurodevelopme ntal outcome (any disability or any BSID II score <70) | 25.2+/-8.4 months corrected age | Control | 67 | | | P-value:0.01 RR:0.53 (0.33-0.87) | chronic lung disease and severe IVH or PVL
Mestan, 2005^3^ | Abnormal neurodevelopme ntal outcome (any disability or any BSID II score <70) | 24.9 +/- 7.9 months corrected age | iNO | 70 | | | P-value:0.01 RR:0.53 (0.33-0.87)
Mestan, 2005^3^ | Abnormal neurodevelopme ntal outcome (any disability or any BSID II score <70) | 25.2+/- 8.4 months corrected age | Control | 67 | | | P-value:0.03 RR:0.6 (0.38-0.96) | prolonged postnatal exposure to corticosteroids
Mestan, 2005^3^ | Abnormal neurodevelopme ntal outcome (any disability or any BSID II score <70) | 24.9 +/- 7.9 months corrected age | iNO | 70 | | | P-value:0.03 RR:0.6 (0.38-0.96) | prolonged postnatal exposure to corticosteroids
Mestan, 2005^3^ | Abnormal neurodevelopme ntal outcome (any disability or any BSID II score <70) | 25.2+/-8.4 months corrected age | Control | 67 | | | P-value:0.01 RR:0.53 (0.33-0.87) | birth weight and sex
Mestan, 2005^3^ | Abnormal neurodevelopme ntal outcome (any disability or any BSID II score <70) | 24.9 +/-7.9 months corrected age | iNO | 70 | | | P-value:0.01 RR:0.53 (0.33-0.87) | birth weight and sex
Mestan, 2005^3^ | Abnormal neurodevelopme ntal outcome (any disability or any BSID II score <70) | 25.2+/- 8.4 months corrected age | Control | 67 | | | P-value:0.01 RR:0.55 (0.35-0.99) | severe intraventricular hemorrhage or periventricular leukomalacia
Mestan, 2005^3^ | Abnormal neurodevelopme ntal outcome (any disability or any BSID II score <70) | 24.9 +/- 7.9 months corrected age | iNO | 70 | | | P-value:0.01 RR:0.55 (0.35-0.99) | severe intraventricular hemorrhage or periventricular leukomalacia
Mestan, 2005^3^ | Abnormal neurodevelopme ntal outcome (any disability or any BSID II score <70) | 25.2+/- 8.4 months corrected age | Control | 67 | | | P-value:0.01 RR:0.55 (0.34-0.89) | chronic lung disease
Mestan, 2005^3^ | Abnormal neurodevelopme ntal outcome (any disability or any BSID II score <70) | 24.9 +/- 7.9 months corrected age | iNO | 70 | | | P-value:0.01 RR:0.55 (0.34-0.89) | chronic lung disease
Mestan, 2005^3^ | Delay without disability | 25.2+/- 8.4 months corrected age | Control | 67 | 23 (34) | | P-value:0.03 RR:0.55 (0.36-0.95)
Mestan, 2005^3^ | Delay without disability | 24.9 +/- 7.9 months corrected age | iNO | 69 | 11 (16) | | P-value:0.03 RR:0.55 (0.36-0.95)
Mestan, 2005^3^ | Disability (CP, bilateral blindness or bilateral hearing loss) | 25.2+/- 8.4 months corrected age | Control | 68 | 8 (12)
Mestan, 2005^3^ | Disability (CP, bilateral blindness or bilateral hearing loss) | 24.9 +/- 7.9 months corrected age | iNO | 67 | 6 (9)
Mestan, 2005^3^ | MDI or PDI < 70 | 25.2+/- 8.4 months corrected age | Control | 67 | 28 (42) | P-value: 0.03
Mestan, 2005^3^ | MDI or PDI < 70 | 24.9 +/- 7.9 months corrected age | iNO | 69 | 16 (23) | P-value: 0.03
Mestan, 2005^3^ | MDI and PDI < 70 | 25.2+/- 8.4 months corrected age | Control | 67 | 8 (12) | P-value: 0.58
Mestan, 2005^3^ | MDI and PDI < 70 | 24.9 +/- 7.9 months corrected age | iNO | 69 | 6 (9) | P-value: 0.58
Van Meurs, 2007^4^ | NDI = any one of the following: moderate to severe CP, blind, deaf, MDI <70, or PDI <70 | 18 to 22 months | Control | 8 | 2 (25) | P-value:0.58 RR: 0.44 (0.05-4,02) | | OI stratum
Van Meurs, 2007^4^ | NDI = any one of the following: moderate to severe CP, blind, deaf, MDI <70, or PDI <70 | 18 to 22 months | iNO | 9 | 1 (11) | P-value:0.58 RR: 0.44 (0.05-4,02) | | OI stratum
Walsh, 2010^5^ | MDI>85 | 2 years | Control | 214 | 83 (35)
Walsh, 2010^5^ | MDI>85 | 24.9 +/- 7.9 months corrected age | iNO | 210 | 95 (45.2)
Walsh, 2010^5^ | PDI>85 | 2 years | Control | 212 | 73 (31)
Walsh, 2010^5^ | PDI>85 | 2 years | iNO | 207 | 75 (36.2)
Walsh, 2010^5^ | NDI in subset with complete evaluations | 2 years | Control | 212 | (51) | RR:0.93 (0.76-1.14)
Walsh, 2010^5^ | NDI in subset with complete evaluations | 2 years | iNO | 207 | (48) | RR:0.93 (0.76-1.14)
Walsh, 2010^5^ | Neurodevelopme ntal Impairment (NDI = MDI<70, PDI<70, unable to crawl or walk (GMFCS>=2), bilateral blindness, or bilateral deafness requiring amplification). | 2 years | Control | 234 | 114 (49) | RR: 0.92 (0.75-1.12)
Walsh, 2010^5^ | Neurodevelopme ntal Impairment (NDI = MDI<70, PDI<70, unable to crawl or walk (GMFCS>=2), bilateral blindness, or bilateral deafness requiring amplification). | 2 years | iNO | 243 | 109 (44.8) | RR: 0.92 (0.75-1.12)

BSID: Bayley Scale of Infant Development, BW: Birth weight, CP: Cerebral Palsy, GCAS: General conceptual ability score, GMFCS: Gross Motor Function Classification System, iNO: Inhaled Nitric Oxide, IQR: Inter-quartile range, IVH: Intravascular hemorrhage, MDI: Mental Development Index, NDI: Neurodevelopmental Impairment, OI: Oxygenation Index, PDI: Psychomotor Development Index, PVL: Periventricular leukomalacia, RR: Relative Risk

Evidence Table 13 Sensory impairment for KQ3

Author, year | Outcome | Time of Outcome Measure | Study Arm | N (Participants Measured) | Number of Participants with Outcome—n (%) | Relative Effect (95% CI) | Adjusted Relative Effect (95% CI) | Adjustments
Bennett, 2001^1^ | Sensorineural Impairment | | Control | 22 | 1 (5)
Bennett, 2001^1^ | Sensorineural Impairment | | iNO | 20 | 0 (0)
Field, 2005^2^ | Visual Impairment | 1 year corrected age | Control | 53 | 0 (0)
Field, 2005^2^ | Visual Impairment | 1 year corrected age | iNO | 55 | 1 (2)
Field, 2005^2^ | Hearing Impairment | 1 year corrected age | Control | 53 | 0 (0)
Field, 2005^2^ | Hearing Impairment | 1 year corrected age | iNO | 55 | 3 (5)
Huddy, 2008^3^ | Visual Impairment | 4-5 years | Control | 16 | 7 (43.7)
Huddy, 2008^3^ | Visual Impairment | 4-5 years | iNO | 22 | 13 (59.1)
Huddy, 2008^3^ | Hearing Impairment | 4-5 years | Control | 16 | 0 (0)
Huddy, 2008^3^ | Hearing Impairment | 4-5 years | iNO | 22 | 2 (9.1)
Mestan KK, 2005^4^ | Hearing Aid | 25.2+/-8.4 months corrected age 24.9+/-7.9 months corrected age | Control | 68 | 1 (1) | P-value: 0.49
Mestan KK, 2005^4^ | Hearing Aid | 25.2+/-8.4 months corrected age 24.9+/-7.9 months corrected age | iNO | 70 | 0 (0)
Mestan KK, 2005^4^ | Blindness | 25.2+/-8.4 months corrected age 24.9+/-7.9 | Control | 68 | 2 (3) | P-value: 0.24
Mestan KK, 2005^4^ | Blindness | 25.2+/-8.4 months corrected age 24.9+/-7.9 | iNO | 70 | 0 (0)
Van Meurs, 2007^5^ | Deafness | 4-5 years | Control | 16 | 0 (0)
Van Meurs, 2007^5^ | Deafness | 4-5 years | iNO | 22 | 1 (4.5)
Van Meurs, 2007^5^ | No recognizable speech | 4-5 years | Control | 16 | 0 (0)
Van Meurs, 2007^5^ | No recognizable speech | 4-5 years | iNO | 22 | 3 (13.6)
Van Meurs, 2007^5^ | Any disability of hearing or communication | 4-5 years | Control | 16 | 3 (18.7)
Van Meurs, 2007^5^ | Any disability of hearing or communication | 4-5 years | iNO | 22 | 3 (13.6)
Van Meurs, 2007^5^ | Deafness | 18 to 22 months | Control | 8 | 0 (0)
Van Meurs, 2007^5^ | Deafness | 18 to 22 months | iNO | 9 | 0 (0)
Walsh, 2010^6^ | Deafness | 2 years | Control | 234 | 3 (1) | RR: 2.56 (0.68-9.52)
Walsh, 2010^6^ | Deafness | 24.9+/-7.9 months corrected age | iNO | 243 | 8 (3.2) | RR: 2.56 (0.68-9.52)
Walsh, 2010^6^ | Blindness | 2 years | Control | 234 | 9 (4) | RR: 0.97 (0.40-2.40)
Walsh, 2010^6^ | Blindness | 24.9+/-7.9 | iNO | 243 | 9 (3.7) | RR: 0.97 (0.40-2.40)
Watson, 2009 7 | Sensory impairment included in NDI but not individually.

CI: Confidence Interval, iNO: Inhaled nitric oxide, NDI: Neurodevelopmental Impairment, RR: Relative Risk

Evidence Table 14 NDI and death or NDI outcomes for KQ3

Author, year | Outcome | Time of Outcome Measure | Study Arm | N (Participants Measured) | Number of Participants with Outcome—n (%) | Relative Effect (95% CI) | Adjusted Relative Effect (95% CI) | Adjustments
Bennett, 2001^1^ | Severe neurodisability - one or more of: moderate or severe developmental delay; CP; sensorineural impairment (hearing loss requiring hearing aids and blindness) | 30 months corrected age | Control | 14 | 5 (36) | P-value: 0.12
Bennett, 2001^1^ | Severe neurodisability - one or more of: moderate or severe developmental delay; CP; sensorineural impairment (hearing loss requiring hearing aids and blindness) | 30 months corrected age | iNO | 7 | 0 (0)
Hintz SR, 2007^2^ | NDI: any of the following: mod-severe CP, blind, deaf, MDI<70 or PDI<70 | 18-22 months | Control | 102 | 48(47) | P-value:0.74 RR: 1.07 (0.80 - 1.44) | | Model #1: BWt,center, OI entry <criterion strata, sex, Model #2: same as model #1 + BPD, IVH gr 3 or 4 or PVL, length of iNO exposure, postnatal steroids
Hintz SR, 2007^2^ | NDI: any of the following: mod-severe CP, blind, deaf, MDI<70 or PDI<70 | 18-22 months | iNO | 89 | 45 (51) | P-value:0.74 RR: 1.07 (0.80 - 1.44) | | Model #1: BWt,center, OI entry <criterion strata, sex, Model #2: same as model #1 + BPD, IVH gr 3 or 4 or PVL, length of iNO exposure, postnatal steroids
Hintz SR, 2007^2^ | Isolated delay = MDI<70 or PDI<70 n absence of mod-severe CP, deafness or blindness | | Control | 102 | 35 (34) | P-value:0.37 RR:0.79 (0.51-1.23) | P-value: Model #1: 0.78: Model #2 0.37 RR: Model #1: 1.04 (0.79-1.36); Model #2: 1.19 (0.81-1.73) | Model #1: BWt, center, OI entry criterion strata, sex
Hintz SR, 2007^2^ | Isolated delay = MDI<70 or PDI<70 n absence of mod-severe CP, deafness or blindness | | iNO | 88 | 24 (27) | P-value:0.37 RR:0.79 (0.51-1.23) | P-value: Model #1: 0.78: Model #2 0.37 RR: Model #1: 1.04 (0.79-1.36); Model #2: 1.19 (0.81-1.73)
Hintz SR, 2007^2^ | Unimpaired = MDI & PDI>85, no mod-severe CP, and not blind or deaf | | Control | 102 | 26 (25) | P-value:0.86 RR:0.92 (0.56-1.51) | P-value: Model #1: 0.10; Model #2 0.43 RR: Model #1: 0.72 (0.48-1.07); Model #2: 0.79 (0.44-1.42) | Model #1: BWt, center, OI entry criterion strata, sex
Huddy, 2008^3^ | Overall outcome: severe disability | 4-5 yrs, median 4.52 (IQR 0.9) | Control | 16 | 3 (18.7)
Huddy, 2008^3^ | Overall outcome: severe disability | 4-5 yrs, median 4.63, IQR 0.84) | iNO | 22 | 3 (13.6)
Huddy, 2008^3^ | Overall outcome: Moderate disability | 4-5 yrs, median 4.52 (IQR 0.9) | Control | 16 | 4 (25)
Huddy, 2008^3^ | Overall outcome: Moderate disability | 4-5 yrs, median 4.63, IQR 0.84) | iNO | 22 | 5 (22.7)
Huddy, 2008^3^ | Overall outcome: Normal | 4-5 yrs, median 4.52 (IQR 0.9) | Control | 16 | 3 (18.7)
Huddy, 2008^3^ | Overall outcome: Normal | 4-5 yrs, median 4.63, IQR 0.84) | iNO | 22 | 5 (22.7)
Huddy, 2008^3^ | Overall outcome: mild disability | 4-5 yrs, median 4.52 (IQR 0.9) | Control | 16 | 4 (25)
Huddy, 2008^3^ | Overall outcome: mild disability | 4-5 yrs, median 4.63, IQR 0.84) | iNO | 22 | 6 (27.3)
Mestan, 2005^4^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 25.2+/-8.4 months corrected age 24.9 +/-7.9 months corrected age | Control | 68 | 31 (46) | P-value:0.01 RR: 0.53 (0.33-0.87) | P-value: Model #1: 0.50: Model #2 0.79 RR: Model #1: 0.85 (0.54-1.35); Model #2: 0.91 (0.46-1.81))
Mestan, 2005^4^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 25.2+/-8.4 months corrected age 24.9 +/-7.9 months corrected age | iNO | 70 | 17 (24) | P-value:0.01 RR: 0.53 (0.33-0.87) | P-value: Model #1: 0.50: Model #2 0.79 RR: Model #1: 0.85 (0.54-1.35); Model #2: 0.91 (0.46-1.81))
Mestan, 2005^4^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 25.2+/-8.4 months corrected age | Control | 68 | | | | birth weight
Mestan, 2005^4^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 24.9 +/-7.9 months corrected age | iNO | 70 | | | | birth weight
Mestan, 2005^4^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 25.2+/-8.4 months corrected age | Control | 68 | | | P-value:0.002 RR:0.57(0.35-0.93 | sex
Mestan, 2005^4^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 24.9 +/-7.9 months corrected age | iNO | 70 | | | P-value:0.002 RR:0.57(0.35-0.93 | sex
Mestan, 2005^4^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 25.2+/-8.4 months corrected age | Control | 68 | | | P-value:0.006 RR:0.52 (0.32-0.82) | Mother graduation from high school
Mestan, 2005^4^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 24.9 +/-7.9 months corrected age | iNO | 70 | | | P-value:0.006 RR:0.52 (0.32-0.82) | Mother graduation from high school
Mestan, 2005^4^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 25.2+/-8.4 months corrected age | Control | 68 | | | P-value:0.007 RR:0.48 (0.28-0.82) | household without employed person
Mestan, 2005^4^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 24.9 +/-7.9 months corrected age | iNO | 70 | | | P-value:0.007 RR:0.48 (0.28-0.82) | household without employed person
Mestan, 2005^4^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 25.2+/-8.4 months corrected age | Control | 68 | | | P-value:0.006 RR:0.49 (0.29-0.82) | type of ventilation
Mestan, 2005^4^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 24.9 +/-7.9 months corrected age | iNO | 70 | | | P-value:0.006 RR:0.49 (0.29-0.82) | type of ventilation
Mestan, 2005^4^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 25.2+/-8.4 months corrected age | Control | 68 | | | P-value:0.01 RR:0.53 (0.33-0.87) | chronic lung disease and severe IVH or PVL
Mestan, 2005^4^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 24.9 +/-7.9 months corrected age | iNO | 70 | | | P-value:0.01 RR:0.53 (0.33-0.87)
Mestan, 2005^4^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 25.2+/-8.4 months corrected age | Control | 68 | | | P-value:0.03 RR:0.6 (0.38-0.96) | prolonged postnatal exposure to corticosteroids
Mestan, 2005^4^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 24.9 +/-7.9 months corrected age | iNO | 70 | | | P-value:0.03 RR:0.6 (0.38-0.96) | prolonged postnatal exposure to corticosteroids
Mestan, 2005^4^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 25.2+/-8.4 months corrected age | Control | 68 | | | P-value:0.01 RR:0.53 (0.33-0.87) | birth weight and sex
Mestan, 2005^4^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 24.9 +/-7.9 months corrected age | iNO | 70 | | | P-value:0.01 RR:0.53 (0.33-0.87) | birth weight and sex
Mestan, 2005^4^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 25.2+/-8.4 months corrected age | Control | 68 | | | P-value:0.01 RR:0.55 (0.35-0.99) | severe intraventricular hemorrhage or periventricular leukomalacia
Mestan, 2005^4^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 24.9 +/-7.9 months corrected age | iNO | 70 | | | P-value:0.01 RR:0.55 (0.35-0.99) | severe intraventricular hemorrhage or periventricular leukomalacia
Mestan, 2005^4^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 25.2+/-8.4 months corrected age | Control | 68 | | | P-value:0.01 RR:0.55 (0.34-0.89) | chronic lung disease
Mestan, 2005^4^ | Abnormal neurodevelopmental outcome (any disability or any BSID II score <70) | 24.9 +/-7.9 months corrected age | iNO | 70 | | | P-value:0.01 RR:0.55 (0.34-0.89) | chronic lung disease
Van Meurs, 2007^5^ | NDI = any one of the following: moderate to severe CP, blind, deaf, MDI <70, or PDI <70 | 18 to 22 months | Control | 8 | 2 (25) | P-value:0.58 RR: 0.44 (0.05-4.02) | | OI stratum
Van Meurs, 2007^5^ | NDI = any one of the following: moderate to severe CP, blind, deaf, MDI <70, or PDI <70 | 18 to 22 months | iNO | 9 | 1 (11) | P-value:0.58 RR: 0.44 (0.05-4.02)
Walsh, 2010^6^ | NDI in subset with complete evaluations | 2 years | Control | 212 | (51) | RR:0.93 (0.76-1.14)
Walsh, 2010^6^ | NDI in subset with complete evaluations | 24.9 +/-7.9 months corrected age | iNO | 207 | (48) | RR:0.93 (0.76-1.14)
Walsh, 2010^6^ | Neuro development al Impairment (NDI = MDI<70, PDI<70, unable to crawl or walk (GMFCS>=2), bilateral blindness, or bilateral deafness requiring amplification). | 2 years | Control | 234 | 114 (49) | RR: 0.92 (0.75-1.12)
Walsh, 2010^6^ | Neuro development al Impairment (NDI = MDI<70, PDI<70, unable to crawl or walk (GMFCS>=2), bilateral blindness, or bilateral deafness requiring amplification). | 2 years | iNO | 243 | 109 (44.8) | RR: 0.92 (0.75-1.12)
Watson, 2009^7^ | NDI (CP, severe hearing loss, MDI or PDI< 70,or blindness) | 1 year corrected age | Control | 218 | 73 (33.5) | P-value: 0.66
Watson, 2009^7^ | NDI (CP, severe hearing loss, MDI or PDI< 70,or blindness) | 1 year corrected age | iNO | 237 | 84 (35.4) | P-value: 0.66
Van Meurs, 2007^5^ | Death or NDI, Death and/or NDI | 18 to 22 months | Control | 12 | 6 (50) | P-value: 1 RR: 0.86 (0.37-1.96) | P-value: 0.8 RR: 0.90 (0.40-2.02) | OI Strata
Van Meurs, 2007^5^ | Death or NDI, Death and/or NDI | 18 to 22 months | iNO | 14 | 6 (43) | P-value: 1 RR: 0.86 (0.37-1.96) | P-value: 0.8 RR: 0.90 (0.40-2.02) | OI Strata
Van Meurs, 2007^5^ | Death or NDI, Death and/or moderate to severe CP | 18 to 22 months | Control | 12 | 4 (33) | P-value: 1 RR: 1.07 (0.37-3.11) | P-value: 0.88 RR: 1.08 (0.39-3.03) | OI Strata
Van Meurs, 2007^5^ | Death or NDI, Death and/or moderate to severe CP | 18 to 22 months | iNO | 14 | 5 (36) | P-value: 1 RR: 1.07 (0.37-3.11) | P-value: 0.88 RR: 1.08 (0.39-3.03) | OI Strata
Bennett, 2001^1^ | Death or NDI, Death or severe neurodisability | 30 months corrected age | Control | 22 | 13 (59) | P-value: 0.79 RR: 1.1 (0.57-2.3)
Bennett, 2001^1^ | Death or NDI, Death or severe neurodisability | 30 months corrected age | iNO | 19 | 12 (63) | P-value: 0.79 RR: 1.1 (0.57-2.3)
Watson, 2009^7^ | Death or NDI, Death or NDI (CP, severe hearing loss, MDI or PDI< 70,or blindness) | 1 year corrected age | Control | 384 | 171 (44.5) | P-value: 0.55
Watson, 2009^7^ | Death or NDI, Death or NDI (CP, severe hearing loss, MDI or PDI< 70,or blindness) | 1 year corrected age | iNO | 387 | 164 (42.4) | P-value: 0.55
Watson, 2009^7^ | Death or NDI, Death, on oxygen, or NDI (CP, severe hearing loss, MDI or PDI< 70,or blindness) | 1 year corrected age | Control | 384 | 175 (45.6) | P-value: 0.65
Watson, 2009^7^ | Death or NDI, Death, on oxygen, or NDI (CP, severe hearing loss, MDI or PDI< 70,or blindness) | 1 year corrected age | iNO | 387 | 170 (43.9) | P-value: 0.65
Hintz SR, 2007^2^ | Death or NDI, Death or NDI:any of the following: mod-severe CP, blind, deaf, MDI<70 or PDI<70 | 18-22 months | Control | 200 | 146 (73) | P-value: 0.32 RR:1.07 (0.95-1.19) | P-value: 0.3 RR: Model #1:1.06 (0.95-1.17) | Model #1: BWt, center, OI entry criterion strata, sex
Hintz SR, 2007^2^ | Death or NDI, Death or NDI:any of the following: mod-severe CP, blind, deaf, MDI<70 or PDI<70 | 18-22 months | iNO | 198 | 154 (78) | P-value: 0.32 RR:1.07 (0.95-1.19) | P-value: 0.3 RR: Model #1:1.06 (0.95-1.17) | Model #1: BWt, center, OI entry criterion strata, sex
Hintz SR, 2007^2^ | Death or NDI, Death or moderate to severe CP | 18-22 months | Control | 200 | 109 (54) | P-value: 0.07 RR: 1.17 (0.99-1.38) | P-value: 0.07 RR: Model #1: 1.15 (0.99-1.34) | Model #1: BWt, center, OI entry criterion strata, sex
Hintz SR, 2007^2^ | Death or NDI, Death or moderate to severe CP | 18-22 months | iNO | 199 | 127 (64) | P-value: 0.07 RR: 1.17 (0.99-1.38) | P-value: 0.07 RR: Model #1: 1.15 (0.99-1.34) | Model #1: BWt, center, OI entry criterion strata, sex

CI: Confidence Interval; CP: Cerebral Palsy; GMFCS: Gross motor function classification system; iNO: Inhaled nitric oxide; IQR: Inter-quartile range; MDI: Mental developmental index; NDI: Neurodevelopmental impairment; NS: Not significant,OI: Oxygenation index; OI: Oxygenation Index; PDI: Physical developmental index;

Evidence Table 15 Other long term outcomes included in KQ3 including seizures, growth, oral feeding, pulmonary outcomes

Refid | Outcome | Time of Outcome Measure | Study Arm | N (Participants Measured) | Number of Participants with Outcome—n (%) | Z-score | Measurement | Relative Effect (95% CI) | Adjusted Relative Effect (95% CI)
Field, 2005^1^ | Seizures | 1 year corrected age | Control | 18 | 0 (0)
Field, 2005^1^ | Seizures | 1 year corrected age | iNO | 25 | 3 (12)
Huddy, 2008^2^ | Seizures | 4-5 years | Control | 16 | 2 (9.1)
Huddy, 2008^2^ | Seizures | 4-5 years | iNO | 22 | 3 (13.6)
Field, 2005^1^ | Oral feeding | 1 year corrected | Control | 53 | 20 (38)
Field, 2005^1^ | Oral feeding | 1 year corrected | iNO | 55 | 28 (51)
Huddy, 2008^2^ | Steroids, Inhaled | 4-5 years | Control | 16 | 3 (18.8)
Huddy, 2008^2^ | Steroids, Inhaled | 4-5 years | iNO | 22 | 4 (18.2)
Field, 2005^1^ | Steroids, Unspecified | 1 year corrected age | Control | 18 | 5 (28)
Field, 2005^1^ | Steroids, Unspecified | 1 year corrected age | iNO | 25 | 5 (20)
Hibbs, 2007^3^ | Steroids, Unspecified | 12 +/- 3 months | Control | 225 | (17.7) | | | OR: 0.5 (0.32-0.77)
Hibbs, 2007^3^ | Steroids, Unspecified | 12 +/- 3 months | iNO | 230 | (11) | | | OR: 0.5 (0.32-0.77)
Hibbs, 2007^3^ | Steroids, Unspecified | 12 +/- 3 months | Control | 225 | (32.4) | | | OR: 0.56 (0.32-0.97)
Hibbs, 2007^3^ | Steroids, Unspecified | 12 +/- 3 months | iNO | 230 | (19.8) | | | OR: 0.56 (0.32-0.97)
Cheung, 1998^4^ | Bronchodilators | | iNO | 10 | 1 (10)
Field, 2005^1^ | Bronchodilators | 1 year corrected age | Control | 18 | 7 (39)
Field, 2005^1^ | Bronchodilators | 1 year corrected age | iNO | 25 | 10 (40)
Hibbs, 2007^3^ | Bronchodilators | 12 +/- 3 months | Control | 225 | (54.1) | | | OR:0.53(0.36-0.78)
Hibbs, 2007^3^ | Bronchodilators | 12 +/- 3 months | iNO | 230 | (40.1) | | | OR:0.53(0.36-0.78)
Huddy, 2008^2^ | Bronchodilators | 4-5 years | Control | 16 | 4 (25)
Huddy, 2008^2^ | Bronchodilators | 4-5 years | iNO | 22 | 7 (31.8)
Hibbs AM, 2007^3^ | Diuretics | 12 +/- 3 months | Control | 225 | (28.4) | | | OR: 0.54 (0.34-0.85)
Hibbs AM, 2007^3^ | Diuretics | 12 +/- 3 months | iNO | 230 | (18.6) | | | OR: 0.54 (0.34-0.85)
Huddy 2008^2^ | Long-Term Pulmonary Outcomes, Asthma | 4-5 yrs, median 4.52 (IQR 0.9) | Control | 16 | 4 (25)
Huddy 2008^2^ | Long-Term Pulmonary Outcomes, Asthma | 4-5 yrs, median 4.63, IQR 0.84) | iNO | 22 | 9 (40.9)
Huddy, 2008^2^ | Long-Term Pulmonary Outcomes, Respiratory Disability | 4-5 yrs | Control | 16 | 1 (6.2)
Huddy, 2008^2^ | Long-Term Pulmonary Outcomes, Respiratory Disability | 4-5 yrs | iNO | 22 | 2 (9.1)
Field, 2005^1^ | Long-Term Pulmonary Outcomes, Feeding tube | 1 year corrected age | Control | 18 | 1 (6)
Field, 2005^1^ | Long-Term Pulmonary Outcomes, Feeding tube | 1 year corrected age | iNO | 25 | 1 (4)
Cheung, 1998^4^ | Long-Term Pulmonary Outcomes, Wheezing | > 1 year corrected age | iNO | 10 | 4 (40)
Field, 2005^1^ | Long-Term Pulmonary Outcomes, Wheezing | 1 year corrected age | Control | 18 | 5 (28)
Field, 2005^1^ | Long-Term Pulmonary Outcomes, Wheezing | 1 year corrected age | iNO | 25 | 13 (52)
Hibbs, 2007^3^ | Long-Term Pulmonary Outcomes, Wheezing | 12 +/- 3 months | Control | 225 | (56.4) | | | OR: 0.7 (0.48-1.03)
Hibbs, 2007^3^ | Long-Term Pulmonary Outcomes, Wheezing | 12 +/- 3 months | iNO | 230 | (49.6) | | | OR: 0.7 (0.48-1.03)
Huddy, 2008^2^ | Long-Term Pulmonary Outcomes, Wheezing | 4-5 yrs, median 4.52 (IQR 0.9) | Control | 16 | 6 (50)
Huddy, 2008^2^ | Long-Term Pulmonary Outcomes, Wheezing | 4-5 yrs, median 4.63, IQR 0.84) | iNO | 22 | 9 (40.9)
Cheung, 1998 4 | Long-Term Pulmonary Outcomes, Recurrent Aspiration Pneumonia | > 1 year corrected age | iNO | 10 | 1 (10)
Clark, 2002^5^ | Long-Term Pulmonary Outcomes, Supplemental Oxygen | 6 months PCA | iNO | 25 | 10 (40)
Field, 2005 1 | Long-Term Pulmonary Outcomes, Supplemental Oxygen | 1 year corrected age | Control | 18 | 1 (6)
Field, 2005 1 | Long-Term Pulmonary Outcomes, Supplemental Oxygen | 1 year corrected age | iNO | 25 | 3 (12)
Hibbs, 2007^3^ | Long-Term Pulmonary Outcomes, Supplemental Oxygen | Any Home | Control | 225 | (49.5)
Hibbs, 2007^3^ | Long-Term Pulmonary Outcomes, Supplemental Oxygen | Oxygen Use | iNO | 230 | (38.4)
Hibbs, 2007^3^ | Long-Term Pulmonary Outcomes, Supplemental Oxygen | Persistent oxygen use at time of followup | Control | 225 | (9.4)
Hibbs, 2007^3^ | Long-Term Pulmonary Outcomes, Supplemental Oxygen | Persistent oxygen use at time of followup | iNO | 230 | (3)
Huddy, 2008^2^ | Long-Term Pulmonary Outcomes, Supplemental Oxygen | 4-5 years (Oxygen discontinued prior to follow-up) | Control | 16 | 4 (25)
Huddy, 2008^2^ | Long-Term Pulmonary Outcomes, Supplemental Oxygen | 4-5 years (Oxygen discontinued prior to follow-up) | iNO | 22 | 4 (18)
Watson, 2009^6^ | Long-Term Pulmonary Outcomes, Supplemental Oxygen | 1 year corrected age 500-749g | Control | 192 | 3 (2)
Watson, 2009^6^ | Long-Term Pulmonary Outcomes, Supplemental Oxygen | 1 year corrected age 500-749g | iNO | 192 | 13 (7)
Watson, 2009^6^ | Long-Term Pulmonary Outcomes, Supplemental Oxygen | 1 year corrected age 750-999g | Control | 139 | 5 (4)
Watson, 2009^6^ | Long-Term Pulmonary Outcomes, Supplemental Oxygen | 1 year corrected age 750-999g | iNO | 141 | 4 (3)
Watson, 2009^6^ | Long-Term Pulmonary Outcomes, Supplemental Oxygen | 1 year corrected age 1000-1250g | Control | 64 | 3 (5)
Watson, 2009^6^ | Long-Term Pulmonary Outcomes, Supplemental Oxygen | 1 year corrected age 1000-1250g | iNO | 65 | 0 (0)
Huddy, 2008^2^ | Height | 4-5 years | Control | 16 | | -0.68
Huddy, 2008^2^ | Height | 4-5 years | iNO | 22 | | -0.9
Mestan KK, 2005^7^ | Height | 2 years | Control | 79 | 68 (86) | -0.59 (IQR -1.25 to 0.41) | Median:83.9 cm IQR 81-88.3 cm | 0.55 | 0.32
Mestan KK, 2005^7^ | Height | 2 years | iNO | 138 | 70 (51) | -0.23 (IQR -0.83 to 0.36) | Median:84.5 cm IQR 81.2-88.5 | 0.55 | 0.32
Walsh, 2010^8^ | Height | 2 Years | Control | 234 | | | Mean: 85.3 cm SD:6 cm
Walsh, 2010^8^ | Height | 2 Years | iNO | 243 | | | Mean: 85.2 cm SD:5.2 cm
Hintz SR, 2007^9^ | Weight | 2 Years | Control | 102 | | | Mean 10.6 kg SD:1.7 kg | 0.72
Hintz SR, 2007^9^ | Weight | 2 Years | iNO | 91 | | | Mean:10.6 kg SD: 1.4 kg | 0.72
Huddy, 2008^2^ | Weight | 4-5 years | Control | 16 | | -1.02
Huddy, 2008^2^ | Weight | 4-5 years | iNO | 22 | | -0.86
Mestan KK, 2005^7^ | Weight | 2 years | Control | 79 | 68 (.86) | -1.07 (IQR -2.25 to -0.38) | Median:10.8 kg IQR 9.5-1 2.2 kg | 0.04 | 0.02
Mestan KK, 2005^7^ | Weight | 2 years | iNO | 138 | 70 () | -0.49 (IQR -1.51 to 0.61 | Median:1.17 kg IQR 1.05-1.35 kg | 0.04 | 0.02
Walsh, 2010^8^ | Weight | 2 Years | Control | 234 | | | Mean: 11.5 kg SD:1.7 kg
Walsh, 2010^8^ | Weight | 2 Years | iNO | 243 | | | Mean: 11.4 kg SD: 1.7
513 Field, 2005^1^ | Head Circumferance | 1 year | Control | 18 | 15 (83) | | Mean:45.2 cm SD:1.6 cm
513 Field, 2005^1^ | Head Circumferance | 1 year | iNO | 25 | 23 (92) | | 45.5 SD:1.8 cm
Hintz SR, 2007^9^ | Head Circumferance | 18-22 Months | Control | 102 | | | Mean:46.7 cm SD:1.9 cm | 0.64
Hintz SR, 2007^9^ | Head Circumferance | 18-22 Months | iNO | 91 | | | Mean:46.8 cm SD:1.7 cm
160 Huddy, 2008^2^ | Head Circumferance | 4-5 years | Control | 16 | | -1.53
160 Huddy, 2008^2^ | Head Circumferance | 4-5 years | iNO | 22 | | -1.48
Walsh, 2010^8^ | Head Circumferance | 2 Years | Control | 234 | | | Mean:47.8 cm SD:1.9 cm
Walsh, 2010^8^ | Head Circumferance | 2 Years | iNO | 243 | | | Mean:47.6 cm SD:2.1 cm
Cheung, 1998 4 | Slow Weight, Height or Head Circumference Development | 1 year | iNO | 10 | 4

CI: Confidence Interval; CP: Cerebral Palsy; iNO: Inhaled Nitric Oxide; IQR: Inter-quartile range; OI: Oxygenation Index; RR: Risk Ratio

Evidence Table 16 All outcomes addressing the KQ4 populations subgroups including death, BPD at 36 weeks PMA, death or BPD, Survival without BPD, Survival with BPD, NDI, death or NDI, Dath, ICH, and PVL, death or disability, cerebral palsy

Author, Year | Outcomes | Time of outcome measure | Study Arm | N (number of participants measured) | Participants with Outcome— n (%) | Relative Effect (95% CI) | Adjusted Relative Effect (95% CI) | Adjustments
Chock, 2009^1^ | BPD at 36 weeks | 36 weeks PMA | Control | 2 | 2 (100) | P-value: 0.43
Chock, 2009^1^ | BPD at 36 weeks | 36 weeks PMA | iNO | 5 | 2 (40) | P-value: 0.43
Field, 2005^2^ | BPD at 36 weeks | 36 weeks PMA | Control | 55 | 15 (27)
Field, 2005^2^ | BPD at 36 weeks | 36 weeks PMA | iNO | 53 | 26 (49)
Kinsella, 2006^3^ | BPD at 36 weeks | 36 weeks PMA | Control | 309 | 210 (68) | P-value: 0.43 | RR:0.96 (0.86–1.09) | randomization strata, study sight
Kinsella, 2006^3^ | BPD at 36 weeks | 36 weeks PMA | iNO | 326 | 212(65) | P-value: 0.43 | RR:0.96 (0.86–1.09) | randomization strata, study sight
Kinsella, 2006^3^ | BPD at 36 weeks | 36 weeks PMA | Control Birth weight of 500–749 g | 189 | 66 (34.9) | | P-value: 0.20 RR: 0.82 (0.61-1.11) | randomization strata, study sight
Kinsella, 2006^3^ | BPD at 36 weeks | 36 weeks PMA | iNO Birth weight of 500–749 g | 191 | 55 (28.8) | | P-value: 0.20 RR: 0.82 (0.61-1.11) | randomization strata, study sight
Kinsella, 2006^3^ | BPD at 36 weeks | 36 weeks PMA | Control Birth weight of 750–999 g | 139 | 24 (17.3) | | P-value: 0.19 RR: 0.63 (0.35-1.15) | randomization strata, study sight
Kinsella, 2006^3^ | BPD at 36 weeks | 36 weeks PMA | iNO Birth weight of 750–999 g | 138 | 15 (10.9) | | P-value: 0.19 RR: 0.63 (0.35-1.15) | randomization strata, study sight
Kinsella, 2006^3^ | BPD at 36 weeks | 36 weeks PMA | Control Birth weight of 1000–1250 g | 64 | 8 (12.5) | | P-value: 0.97 RR: 0.98 (0.39-2.46) | randomization strata, study sight
Kinsella, 2006^3^ | BPD at 36 weeks | 36 weeks PMA | iNO Birth weight of 1000–1250 g | 65 | 8 (12.3) | | P-value: 0.97 RR: 0.98 (0.39-2.46) | randomization strata, study sight
Schreiber, 2003^4^ | BPD at 36 weeks | 36 weeks PMA | Control | 102 | 42 (53.2) | | P-value: 0.07 RR: 0.74 (0.53–1.03) | type of ventilation
Schreiber, 2003^4^ | BPD at 36 weeks | 36 weeks PMA | iNO | 105 | 35 (39.3) | | P-value: 0.07 RR: 0.74 (0.53–1.03) | type of ventilation
Van Meurs, 2005^5^ | BPD at 36 weeks | 36 weeks PMA | Control | 127 | 86 (68) | P-value: 0.26 | RR: 0.90 (0.75–1.08) | center, birth-weight group, and oxygenation-index stratum
Van Meurs, 2005^5^ | BPD at 36 weeks | 36 weeks PMA | iNO | 109 | 65 (60) | P-value: 0.26 | RR: 0.90 (0.75–1.08) | center, birth-weight group, and oxygenation-index stratum
Van Meurs, 2005^5^ | BPD at 36 weeks | 36 weeks PMA | Control BW<=1000g | 88 | 64 (73) | P-value: 0.84 | RR: 1.02 (0.85–1.23) | center, birth-weight group, and oxygenation-index stratum
Van Meurs, 2005^5^ | BPD at 36 weeks | 36 weeks PMA | Arm B BW<=1000 g | 67 | 49 (73) | P-value: 0.84 | RR: 1.02 (0.85–1.23) | center, birth-weight group, and oxygenation-index stratum
Van Meurs, 2005^5^ | BPD at 36 weeks | 36 weeks PMA | Control BW>1000 g | 37 | 21( 57) | P-value: 0.08 | RR: 0.68 (0.45–1.05) | center, birth-weight group, and oxygenation-index stratum
Van Meurs, 2005^5^ | BPD at 36 weeks | 36 weeks PMA | iNO BW> 1000g | 42 | 16 (38) | P-value: 0.08 | RR: 0.68 (0.45–1.05) | center, birth-weight group, and oxygenation-index stratum
Van Meurs, 2005^5^ | BPD at 36 weeks | 36 weeks PMA | Control OI<=17 | 76 | 50 (66) | P-value: 0.12 | RR: 0.80 (0.61–1.06) | center, birth-weight group, and oxygenation-index stratum
Van Meurs, 2005^5^ | BPD at 36 weeks | 36 weeks PMA | iNO OI<=17 | 59 | 30 (51) | P-value: 0.12 | RR: 0.80 (0.61–1.06) | center, birth-weight group, and oxygenation-index stratum
Van Meurs, 2005^5^ | BPD at 36 weeks | 36 weeks PMA | Control OI>17 | 49 | 36 (72) | P-value: 0.85 | RR: 0.98 (0.77–1.24) | center, birth-weight group, and oxygenation-index stratum
Van Meurs, 2005^5^ | BPD at 36 weeks | 36 weeks PMA | iNO OI>17 | 50 | 35 (70) | P-value: 0.85 | RR: 0.98 (0.77–1.24) | center, birth-weight group, and oxygenation-index stratum
Ballard, 2006^6^ | Survival without BPD | 36 weeks PMA | Control | 288 | 105 (36.5) | P-value: 0.04 RR: 1.45 (1.03-2.04)
Ballard, 2006^6^ | Survival without BPD | 36 weeks PMA | iNO | 294 | 129 (43.9) | P-value: 0.04 RR: 1.45 (1.03-2.04)
Ballard, 2006^6^ | Survival without BPD | 36 weeks PMA | Control 500-799 g) | 197 | 74 (37.6) | P-value: 0.07 RR: 1.20 (0.94–1.54)
Ballard, 2006^6^ | Survival without BPD | 36 weeks PMA | iNO 500-799 g | 197 | 85 (43.1) | P-value: 0.07 RR: 1.20 (0.94–1.54)
Ballard, 2006^6^ | Survival without BPD | 36 weeks PMA | Control 800-1250 grams birth weight) | 91 | 32 (35.2) | P-value: 0.14 RR: 1.30 (0.91-1.87)
Ballard, 2006^6^ | Survival without BPD | 36 weeks PMA | iNO 800-1250 grams birth weight | 97 | 44 (45.4) | P-value: 0.14 RR: 1.30 (0.91-1.87)
Ballard, 2006^6^ | Survival without BPD | 36 weeks PMA | Control OI at study entry < 3.5 | 149 | 68 (45.6) | RR: 1.28(1.02-1.61)
Ballard, 2006^6^ | Survival without BPD | 36 weeks PMA | iNO OI at study entry < 3.5 | 162 | 92 (56.8) | RR: 1.28(1.02-1.61)
Ballard, 2006^6^ | Survival without BPD | 36 weeks PMA | Control OI at study entry >= 3.5) | 139 | 37 (26.6) | RR: 1.11(0.74-1.66)
Ballard, 2006^6^ | Survival without BPD | 36 weeks PMA | iNO OI at study entry>= 3.5 | 132 | 37 (28) | RR: 1.11(0.74-1.66)
Schreiber, 2003^4^ | Survival without BPD | Survived NICU | Control | 79 | 37 (46.8)
Schreiber, 2003^4^ | Survival without BPD | Survived NICU | iNO | 89 | 54 (60.7)
Schreiber, 2003^4^ | Survival without BPD | Survived NICU | Control BW<=750 g | 40 | 4 (10)
Schreiber, 2003^4^ | Survival without BPD | Survived NICU | iNO BW<=750 g | 32 | 7 (21.9)
Schreiber, 2003^4^ | Survival without BPD | Survived NICU | iNO BW 751-1000 g | 28 | 14 (50)
Schreiber, 2003^4^ | Survival without BPD | Survived NICU | Control BW 751-1000 g | 29 | 11 (37.9)
Schreiber, 2003^4^ | Survival without BPD | Survived NICU | Control BW 1001-1500 g | 21 | 12 (57.1)
Schreiber, 2003^4^ | Survival without BPD | Survived NICU | iNO BW 1001-1500 g | 30 | 18 (60)
Schreiber, 2003^4^ | Survival without BPD | Survived NICU | Control BW >1500 g | 12 | 10 (83.3)
Schreiber, 2003^4^ | Survival without BPD | Survived NICU | iNO BW 1500 g | 15 | 15 (100)
Schreiber, 2003^4^ | Survival without BPD | Survived NICU | Control OI<6.94 (median) | 49 | 16 (32.7)
Schreiber, 2003^4^ | Survival without BPD | Survived NICU | iNO OI<6.94 (median) | 50 | 32 (64)
Schreiber, 2003^4^ | Survival without BPD | Survived NICU | Control OI>=6.94 (median) | 48 | 20 (41.7)
Schreiber, 2003^4^ | Survival without BPD | Survived NICU | iNO 0I>=6.94 (median)) | 51 | 21 (41.2)
Schreiber, 2003^4^ | Survival with BPD | Survived NICU | Control | 102 | 42 (53.2) | p-value = 0.07 RR = 0.74 (0.53-1.03) | 0.75 (0.54-1.05)
Schreiber, 2003^4^ | Survival with BPD | Survived NICU | iNO | 105 | 35 (39.3) | p-value = 0.07 RR = 0.74 (0.53-1.03) | 0.75 (0.54-1.05)
Banks, 1999^7^ | Death | 3-24 months from enrollment | iNO | 16 | 7 (44)
Banks, 1999^7^ | Death | 3-24 months from enrollment | iNO responders | 11 | 4 (36)
Banks, 1999^7^ | Death | 3-24 months from enrollment | iNO non-responders | 5 | 3 (60)
Chock, 2009^1^ | Death | Death prior to discharge home or within 365 days | Control | 6 | 4 (67) | P-value: 0.57
Chock, 2009^1^ | Death | Death prior to discharge home or within 365 days | iNO | 6 | 2 (33) | P-value: 0.57
Field, 2005^2^ | Death | 36 weeks | Control | 53 | 34 (64)
Field, 2005^2^ | Death | 36 weeks | iNO | 55 | 30 (55)
Hintz SR, 2007^8^ | Death | 18-22 months | Control Birth weight</= 1 000g, F/U cohort | 152 | 79 (52) | P-value: 0.04 | RR: 1.22 (1.10- | OI criterion, birth weight, study center, sex
Hintz SR, 2007^8^ | Death | 18-22 months | iNO tx, Birth weight </=1000gm | 152 | 98 (64) | | | OI criterion, birth weight, study center, sex
Hintz SR, 2007^8^ | Death | 18-22 months | Control Birth weight >1000g, F/U Cohort | 48 | 19 (40) | P-value: 0.08-1.46) | RR: 0.58 (0.31-1.07) | OI criterion, birth weight, study center, sex
Hintz SR, 2007^8^ | Death | 18-22 months | iNO Tx, Birth weight > 1000g | 48 | 11 (23) | | | OI criterion, birth weight, study center, sex
Hintz SR, 2007^8^ | Death | 18-22 months | Control Placebo, Birth weight 401-750grams | 99 | 55 (56) | P-value: 0.01 | | OI criterion, birth weight, study center, sex
Hintz SR, 2007^8^ | Death | 18-22 months | iNO tx, Birth weight 401-750grams | 94 / 400 (for analysis cohort) | 69 (73) | | | OI criterion, birth weight, study center, sex
Hintz SR, 2007^8^ | Death | 18-22 months | Control Placebo, Birth weight 751-1000grams | 53 | 24 (45) | P-value: 0.63 | | OI criterion, birth weight, study center, sex
Hintz SR, 2007^8^ | Death | 18-22 months | iNO tx, Birth weight 751-1000grams) | 58 / 400 (analysis cohort) | 29 (50) | | | OI criterion, birth weight, study center, sex
Hintz SR, 2007^8^ | Death | 18-22 months | Control Placebo, Birth weight 1001-1500 grams | 48 / 400 (analysis cohort) | 19 (40) | P-value: 0.07 | | OI criterion, birth weight, study center, sex
Hintz SR, 2007^8^ | Death | 18-22 months | iNO tx. Birth eight 1001-1500grams | 48 / 400 (analysis cohort) | 11 (23) | | | OI criterion, birth weight, study center, sex
Kinsella, 2006^3^ | Death | 36 wks PMA | Control | 392 | 98 (25) | | P-value: 0.08 RR: 0.79 (0.61-1.03) | randomization strata, study sight
Kinsella, 2006^3^ | Death | 36 wks PMA | iNO | 394 | 78 (19.8) | | P-value: 0.08 RR: 0.79 (0.61-1.03) | randomization strata, study sight
Kinsella, 2006^3^ | Death | 36 wks PMA | Control BW 500-749 g; mean 639, SD 71 | 189 | 66 (34.9) | | P-value:0.2 RR: 0.82 (0.61-1.11) | randomization strata, study sight
Kinsella, 2006^3^ | Death | 36 wks PMA | iNO BW 500-749 g; mean 642, SD 76 | 191 | 55 (28.8) | | P-value:0.2 RR: 0.82 (0.61-1.11) | randomization strata, study sight
Kinsella, 2006^3^ | Death | 36 wks PMA | Control BW 750-999 g; mean 843, SD 71 | 139 | 24 (17.3) | | P-value: 0.13 RR: 0.63 (0.35-1.15) | randomization strata, study sight
Kinsella, 2006^3^ | Death | 36 wks PMA | iNO BW 750-999 g; mean 851, SD 71 | 138 | 15 (10.9) | | P-value: 0.13 RR: 0.63 (0.35-1.15) | randomization strata, study sight
Kinsella, 2006^3^ | Death | 36 wks PMA | Control BW 1000-1250 g; mean 1113 g, SD 77g | 64 | 8 (12.5) | | P-value: 0.97 RR: 0.98 (0.39-2.46) | randomization strata, study sight
Kinsella, 2006^3^ | Death | 36 wks PMA | iNO BW 1000-1250 g; mean 1129 g, SD 68g | 65 | 8 (12.3) | | P-value: 0.97 RR: 0.98 (0.39-2.46) | randomization strata, study sight
Kumar, 2007^9^ | Death | | Control
Kumar, 2007^9^ | Death | | iNO | 23
Schreiber, 2003^4^ | Death | NICU | Control | 102 | 23 (22.5) | | P-value: 0.18 RR: 0.68 (0.38-1.20) | type of ventilation
Schreiber, 2003^4^ | Death | NICU | iNO | 105 | 16 (15.2) | | P-value: 0.18 RR: 0.68 (0.38-1.20) | type of ventilation
Van Meurs, 2005^5^ | Death | Death before discharge to home or within 365 days among hospitalized infants | Control | 208 | 93 (44) | | P-value: 0. 11 RR: 1.16 (0.96-1.39) | birth weight, study center, Oxygenation index
Van Meurs, 2005^5^ | Death | Death before discharge to home or within 365 days among hospitalized infants | iNO | 210 | 109 (52) | | P-value: 0. 11 RR: 1.16 (0.96-1.39) | birth weight, study center, Oxygenation index
Van Meurs, 2005^5^ | Death | Death before discharge to home or within 3 65 days among hospitalized infants | Control BW<=1000g | 158 | 76 (48) | | P-value: 0.01 RR: 1.28 (1.06-1.54) | birth weight, study center, Oxygenation index
Van Meurs, 2005^5^ | Death | Death before discharge to home or within 3 65 days among hospitalized infants | iNO BW<=1000 g | 158 | 98 (62) | | P-value: 0.01 RR: 1.28 (1.06-1.54) | birth weight, study center, Oxygenation index
Van Meurs, 2005^5^ | Death | Death before discharge to home or within 365 days among hospitalized infants | Control BW>1000 g) | 52 | 17 (33) | | P-value: 0.16 RR: 0.65 (0.36-1.18) | birth weight, study center,Oxygenation index
Van Meurs, 2005^5^ | Death | Death before discharge to home or within 365 days among hospitalized infants | iNO BW>1000g | 52 | 11 (21) | | P-value: 0.16 RR: 0.65 (0.36-1.18) | birth weight, study center,Oxygenation index
Van Meurs, 2005^5^ | Death | Death before discharge to home or within 365 days among hospitalized infants | Control OI<=17 | 110 | 40 (36) | | P-value: 0.09 RR: 1.27 (0.96-1.68) | birth weight, study center, Oxygenation index
Van Meurs, 2005^5^ | Death | Death before discharge to home or within 365 days among hospitalized infants | iNO OI<=17 | 100 | 45 (45) | | P-value: 0.09 RR: 1.27 (0.96-1.68) | birth weight, study center, Oxygenation index
Van Meurs, 2005^5^ | Death | Death before discharge to home or within 365 days among hospitalized infants | Control OI>17 | 100 | 53 (53) | | P-value: 0.39 RR: 1.11 (0.88-1.4) | birth weight, study center, Oxygenation index
Van Meurs, 2005^5^ | Death | Death before discharge to home or within 365 days among hospitalized infants | iNO OI>17 | 110 | 64 (58) | | P-value: 0.39 RR: 1.11 (0.88-1.4) | birth weight, study center, Oxygenation index
Yadav, 1999^10^ | Death | Prior to hospital discharge | iNO | 41 | 25 (61)
Yadav, 1999^10^ | Death | Prior to hospital discharge | iNO responders to iNO based on decrease in IO by 10 in first 60 minutes of treatment | 26 | 11 (42)
Yadav, 1999^10^ | Death | Prior to hospital discharge | iNO noesponders based on failure to decrease OI by 10 in 60 minutes of treatment | 15 | 14 (93)
Chock, 2009^1^ | Death or BPD | Death prior to discharge home or within 365 days | Control | 6 | 6 (100) | P-value: 0.18
Chock, 2009^1^ | Death or BPD | Death prior to discharge home or within 365 days | iNO | 6 | 3 (50) | P-value: 0.18
Field, 2005^2^ | Death or BPD | 36 weeks PMA | Control | 53 | 48 (91) | | | Diagnosis, OI severity
Field, 2005^2^ | Death or BPD | 36 weeks PMA | iNO | 55 | 49(89) | | | Diagnosis, OI severity
Field, 2005^2^ | Death or BPD | 36 weeks PMA | Control acute diagnosis at study entry(lung disease immediately after birth and randomizing at <= 3 days) | 36 | 32 (89) | | RR: 0.98(0.87-1.11) | Diagnosis, OI severity
Field, 2005^2^ | Death or BPD | 36 weeks PMA | iNO acute diagnosis at study entry(lung disease immediately after birth and randomizing at <= 3 days) | 35 | 30 (86) | | RR: 0.98(0.87-1.11) | Diagnosis, OI severity
Field, 2005^2^ | Death or BPD | 36 weeks PMA | Control chronic diagnosis (presenting with lung disease immediately after birth with continuing problems and randomizing >3 days)) | 9 | 9 (100) | | | Diagnosis, OI severity
Field, 2005^2^ | Death or BPD | 36 weeks PMA | iNO chronic diagnosis (presenting with lung disease immediately after birth with continuing problems and randomizing >3 days)) | 10 | 10 (100) | | | Diagnosis, OI severity
Field, 2005^2^ | Death or BPD | 36 weeks PMA | Control other diagnosis (developed lung disease after initial recovery from respiratory problems) | 8 | 7 (88) | | RR: 0.98(0.87-1.12) | Diagnosis, OI severity
Field, 2005^2^ | Death or BPD | 36 weeks PMA | iNO other diagnosis (developed lung disease after initial recovery fromrespiratory problems) | 10 | 9 (10) | | RR: 0.98(0.87-1.12) | Diagnosis, OI severity
Field, 2005^2^ | Death or BPD | 36 weeks PMA | Control OI<=30 at study entry | 25 | 22 (88) | | | Diagnosis, OI severity
Field, 2005^2^ | Death or BPD | 36 weeks PMA | iNO OI<=30 at study entry | 25 | 22 (88) | | | Diagnosis, OI severity
Field, 2005^2^ | Death or BPD | 36 weeks PMA | Control OI>30 at study entry | 28 | 26 (93) | | RR: 0.98(0.87-1.12) | Diagnosis, OI severity
Field, 2005^2^ | Death or BPD | 36 weeks PMA | iNO OI>30 at study entry | 30 | 27 (90) | | RR: 0.98(0.87-1.12) | Diagnosis, OI severity
Field, 2005^2^ | Death or BPD | Term EDC | Control acute diagnosis at study entry(lung disease immediately after birth and randomizing at <= 3 days) | 36 | 29 (81)
Field, 2005^2^ | Death or BPD | Term EDC | iNO acute diagnosis at study entry(lung disease immediately after birth and randomizing at <= 3 days) | 35 | 22 (63)
Field, 2005^2^ | Death or BPD | Term EDC | Control chronic diagnosis (presenting with lung disease immediately after birth with continuing problems and randomizing >3 days) | 9 | 9 (100)
Field, 2005^2^ | Death or BPD | Term EDC | iNO chronic diagnosis (presenting with lung disease immediately after birth with continuing problems and randomizing >3 days) | 10 | 10 (100)
Field, 2005^2^ | Death or BPD | Term EDC | Control other diagnosis (developed lung disease after initial recovery from respiratory problems) | 8 | 7 (88)
Field, 2005^2^ | Death or BPD | Term EDC | iNO other diagnosis (developed lung disease after initial recovery from respiratory problems) | 10 | 7 (70)
Field, 2005^2^ | Death or BPD | Term EDC | Control OI<=30 at study entry | 25 | 20 (80)
Field, 2005^2^ | Death or BPD | Term EDC | iNO OI<=30 at study entry | 25 | 17 (68)
Field, 2005^2^ | Death or BPD | | Control OI>30 at study entry | 28 | 25 (89)
Field, 2005^2^ | Death or BPD | | iNO OI>30 at study entry | 30 | 22 (73)
Kinsella, 2006^3^ | Death or BPD | 36 wks PMA | Control | 392 | 295 (75.3) | | P-value: 0.24 RR: 0.95 (0.87-1.03) | study sight, randomization strata
Kinsella, 2006^3^ | Death or BPD | 36 wks PMA | iNO | 394 | 282 (71.6) | | | study sight, randomization strata
Kinsella, 2006^3^ | Death or BPD | 36 wks PMA | Control BW 500-749 g; mean 639, SD 71) | 189 | 159 (84.1) | | P-value: 0.85 RR: 1.01 (0.92-1.1) | study sight, randomization strata
Kinsella, 2006^3^ | Death or BPD | 36 wks PMA | iNO BW 500-749 g; mean 642, SD 76 | 191 | 162 (84.8) | | | study sight, randomization strata
Kinsella, 2006^3^ | Death or BPD | 36 wks PMA | Control BW 750-999 g; mean 843, SD 71 | 139 | 95 (68.3) | | P-value: 0.93 RR: 1.01 (0.86-1.18) | study sight, randomization strata
Kinsella, 2006^3^ | Death or BPD | 36 wks PMA | iNO BW 750-999 g; mean 851, SD 71 | 138 | 95 (68.8) | | | study sight, randomization strata
Kinsella, 2006^3^ | Death or BPD | 36 wks PMA | Control BW 1000-1250 g; mean 1113 g, SD 77 g) | 64 | 41 (64.1) | | P-value: 0.004 RR: 0.6 (0.42-0.86) | study sight, randomization strata
Kinsella, 2006^3^ | Death or BPD | 36 wks PMA | BW 1000-1250 g; mean 1129 g, SD 68g | 65 | 25 (38.5) | | | study sight, randomization strata
Schreiber, 2003^4^ | Death or BPD | Survived NICU | Control | 102 | 51 (48.6) | p = 0.03 RR = 0.76 (0.60-0.97) | 0.77 (0.60-0.98)
Schreiber, 2003^4^ | Death or BPD | Survived NICU | iNO | 105 | 65 (63.7) | p = 0.03 RR = 0.76 (0.60-0.97) | 0.77 (0.60-0.98)
Van Meurs, 2007^11^ | Death or BPD | Death before discharge to home or within 365 | Control | 15 | 9 (60) | P-value: 0.87 RR: 0.83 (0.43-1.62) | p-value: 0.5 RR: 0.80 (0.43-1.48) | OI Stratum
Van Meurs, 2007^11^ | Death or BPD | Death before discharge to home or within 365 | iNO | 14 | 7 (50) | P-value: 0.87 RR: 0.83 (0.43-1.62) | | OI Stratum
Van Meurs, 2005^5^ | Death or BPD | Before discharge to home or within 365 days among hospitalized infants | Control | 208 | 170 (82) | | P-value: 0.52 RR: 0.97 (0.86-1.06) | Birth weight , study site, Oxygenation index
Van Meurs, 2005^5^ | Death or BPD | Before discharge to home or within 365 days among hospitalized infants | iNO | 210 | 167 (80) | | | Birth weight , study site, Oxygenation index
Van Meurs, 2005^5^ | Death or BPD | Before discharge to home or within 365 days among hospitalized infants | Control BW<=1000 g | 158 | 133 (85) | | P-value: 0.29 RR: 1.04 (0.96-1.13) | Birth weight , study site, Oxygenation index
Van Meurs, 2005^5^ | Death or BPD | Before discharge to home or within 365 days among hospitalized infants | iNO BW<=1000 g | 158 | 141 (89) | | | Birth weight , study site, Oxygenation index
Van Meurs, 2005^5^ | Death or BPD | Before discharge to home or within 365 days among hospitalized infants | Control BW<=1000g | 52 | 35 (69) | | P-value: 0.03 RR: 0.72 (0.54-0.96) | Birth weight , study site, Oxygenation index
Van Meurs, 2005^5^ | Death or BPD | Before discharge to home or within 365 days among hospitalized infants | iNO BW>1000 g | 52 | 26 (50) | | | Birth weight , study site, Oxygenation index
Van Meurs, 2005^5^ | Death or BPD | Before discharge to home or within 365 days among hospitalized infants | Control OI<=17 | 110 | 83 (75) | | P-value: 0.37 RR: 0.93 (0.81-1.08) | Birth weight , study site, Oxygenation index
Van Meurs, 2005^5^ | Death or BPD | Before discharge to home or within 365 days among hospitalized infants | iNO OI<=17 | 100 | 71 (71) | | | Birth weight , study site, Oxygenation index
Van Meurs, 2005^5^ | Death or BPD | Before discharge to home or within 365 days among hospitalized infants | Control OI>17 | 100 | 85 (86) | | P-value: 0.75 RR: 1.02 (0.92-1.12) | Birth weight , study site, Oxygenation index
Van Meurs, 2005^5^ | Death or BPD | Before discharge to home or within 365 days among hospitalized infants | iNO OI>17 | 110 | 96 (87) | | | Birth weight , study site, Oxygenation index
Watson, 2009^12^ | Death or BPD | 1 year corrected age | Control | 383 | 110 (28.7) | P-value: 0.29
Watson, 2009^12^ | Death or BPD | 1 year corrected age | iNO | 384 | 97 (25.3) | P-value: 0.29
Watson, 2009^12^ | Death or BPD | 1 year corrected age | Control birth weight 500-749 g | 187 | 70 (37.4) | P-value: 0.99
Watson, 2009^12^ | Death or BPD | 1 year corrected age | iNO birth weight 500-749 g | 187 | 70 (37.4) | P-value: 0.99
Watson, 2009^12^ | Death or BPD | 1 year corrected age | Control birth weight 750-999 g | 133 | 29 (21.8) | P-value: 0.08
Watson, 2009^12^ | Death or BPD | 1 year corrected age | iNO birth weight 750-999 g | 139 | 19 (13.7) | P-value: 0.08
Watson, 2009^12^ | Death or BPD | 1 year corrected age | Controlbirth weight 1000-1250 g | 64 | 11 (17.2) | P-value: 0.61
Watson, 2009^12^ | Death or BPD | 1 year corrected age | iNO birth weight 1000-1250 g | 58 | 8 (13.8) | P-value: 0.61
Van Meurs, 2005^5^ | Brain Injury, Severe IVH (grades 3-4) or PVL | 36 weeks | Control | 210 | 50 (32) | p-value = 0.11 RR= 1.25 (0.95-1.66)
Van Meurs, 2005^5^ | Brain Injury, Severe IVH (grades 3-4) or PVL | 36 weeks | iNO | 210 | 69 (39) | p-value = 0.11 RR= 1.25 (0.95-1.66)
Kinsella, 2006^3^ | Death or Brain Injury, Death or grade 3 or 4 ICH or PVL | 30 days | Control | 391 | 151 (38.6) | | P-value: 0.02 RR: 0.79 (0.65-0.96) | study site, randomization
Kinsella, 2006^3^ | Death or Brain Injury, Death or grade 3 or 4 ICH or PVL | 30 days | iNO | 392 | 120 (30.6) | | | study site, randomization
Kinsella, 2006^3^ | Death or Brain Injury, Death or grade 3 or 4 ICH or PVL | 30 days | Control BW 500-749 g; mean 639, SD 71 | 189 | 89 (47.1) | | P-value: 0.18 RR: 0.86 (0.68-1.08) | study site, randomization
Kinsella, 2006^3^ | Death or Brain Injury, Death or grade 3 or 4 ICH or PVL | 30 days | iNO BW 500-749 g; mean 642, SD 76 | 191 | 77 (40.3) | | | study site, randomization
Kinsella, 2006^3^ | Death or Brain Injury, Death or grade 3 or 4 ICH or PVL | 30 days | Control BW 750-999 g; mean 843, SD 71 | 139 | 47 (33.8) | | P-value: 0.02 RR: 0.63 (0.42-0.93) | study site, randomization
Kinsella, 2006^3^ | Death or Brain Injury, Death or grade 3 or 4 ICH or PVL | 30 days | iNO BW 750-999 g; mean 851, SD 71) | 137 | 29 (21.2) | | | study site, randomization
Kinsella, 2006^3^ | Death or Brain Injury, Death or grade 3 or 4 ICH or PVL | 30 days | Control BW 1000-1250 g; mean 1113 g, SD 77 g | 63 | 15 (23.8) | | P-value: 0.8 RR: 0.92 (0.48-1.74) | study site, randomization
Kinsella, 2006^3^ | Death or Brain Injury, Death or grade 3 or 4 ICH or PVL | 30 days | iNO BW1000-1250 g; mean 1129 g, SD 68 g) | 64 | 14 (21.9)
Field, 2005^2^ | Death or NDI | 1 year corrected | Control acute diagnosis at study entry(lung disease immediately after birth and randomizing at <= 3 days) | 36 | 24 (67) | | RR: 0.99(0.76-1.28) | diagnosis, OI severity
Field, 2005^2^ | Death or NDI | 1 year corrected | iNO acute diagnosis at study entry(lung disease immediately after birth and randomizing at <= 3 days) | 35 | 23 (66) | | | diagnosis, OI severity
Field, 2005^2^ | Death or NDI | 1 year corrected | Control chronic diagnosis (presenting with lung disease immediately after birth with continuing problems and randomizing >3 days)) | 9 | 7 (78) | | | diagnosis, OI severity
Field, 2005^2^ | Death or NDI | 1 year corrected | iNO chronic diagnosis (presenting with lung disease immediately after birth with continuing problems and randomizing >3 days)) | 10 | 8 (10) | | | diagnosis, OI severity
Field, 2005^2^ | Death or NDI | 1 year corrected | Control other diagnosis (developed lung disease after initial recovery from respiratory problems) | 8 | 5 (63) | | | diagnosis, OI severity
Field, 2005^2^ | Death or NDI | 1 year corrected | iNO other diagnosis (developed lung disease after initial recovery from respiratory problems) | 10 | 6 (60) | | | diagnosis, OI severity
Field, 2005^2^ | Death or NDI | 1 year corrected | Control OI<=30 at study entry | 25 | 15 (60) | RR: 0.99(0.76-1.28) | | diagnosis, OI severity
Field, 2005^2^ | Death or NDI | 1 year corrected | iNO OI<=30 at study entry | 25 | 16 (64) | | | diagnosis, OI severity
Field, 2005^2^ | Death or NDI | 1 year corrected | Control OI>30 at study entry | 28 | 21 (75)
Field, 2005^2^ | Death or NDI | 1 year corrected | iNO OI>30 at study entry | 30 | 21 (70)
Field, 2005^2^ | Death or NDI | 1 year corrected | iNO | 387 | 164 (42.4)
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | Control | 196 | 146 (73) | P-value: 0.32 RR: 1.07(0.95-1.19) | P-value: 0.3 RR: Model #1:1.06 (0.95-1.17) | Model #1: Birth weight, center, OI entry criterion strata, sex
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | iNO | 198 | 154 (78) | P-value: 0.32 RR: 1.07(0.95-1.19) | | Model #1: Birth weight, center, OI entry criterion strata, sex
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | Control Birth weight </=1000g, F/U cohort | 152 | 120 (79) | | P-value: 0.12 RR: 1.08 (0.98-1.20) | OI criterion, center, and sex
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | iNO tx, Birth weight </= 1000gm | 151 | 131 (87) | | | OI criterion, center, and sex
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | Control Birth weight >1000g, F/U Cohort | 48 | 26 (54) | | P-value: 0.63 RR: 0.91 (0.63-1.33) | OI criterion, center, and sex
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | iNO Tx, Birth weight >1000g | 47 | 23 (49) | | | OI criterion, center, and sex
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | Control Placebo, Birth weight 401-750grams | 99 / 400 (analysis cohort) | 81 (82) | | P-value 0.051 | OI criterion, center, and sex Birth weight, center, OI entry criterion strata, sex
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | iNO tx, Birth weight 401-750grams | 94 / 400 (for analysis cohort) | 86 (91) | | | OI criterion, center, and sex Birth weight, center, OI entry criterion strata, sex
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | Control Placebo, Birth weight 751-1000grams | 53 | 39 (74) | | P-value: 0.51 | OI criterion, center, and sex Birth weight, center, OI entry criterion strata, sex
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | iNO tx, Birth weight 751-1000grams | 58 / 400 (analysis cohort) | 45 / 57 (79) | | | OI criterion, center, and sex Birth weight, center, OI entry criterion strata, sex
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | Control Placebo, Birth weight 1001-1500 grams | 48 / 400 (analysis group) | 26 (54) | | P-value: 0.54 | OI criterion, center, and sex Birth weight, center, OI entrycriterion strata, sex
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | iNO tx. Birth weight 1001-1500grams | 48 / 400 (analysis group) | 23 / 47 (49) | | | OI criterion, center, and sex Birth weight, center, OI entrycriterion strata, sex
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | Control | 200 | 109 (54) | P-value: 0.07 1.17 RR:(0.99-1.38) | P-value: 0.07 RR: Model #1:1.15 (0.99-1.34) | OI criterion, center, and sex Birth weight, center, OI entry criterion strata, sex
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | iNO | 199 | 127 (64) | P-value: 0.07 1.17 RR:(0.99-1.38) | | OI criterion, center, and sex Birth weight, center, OI entry criterion strata, sex
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | Control Birth weight </= 1000g, F/U cohort | 152 | 89 (59) | P-value: 0.01 | RR: 1.22 (1.05-1.43) | OI criterion, center, and sex Birth weight, center, OI entry criterion strata, sex
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | iNO tx, Birth weight </= 1000gm | 152 | 111/151 (74) | P-value: 0.01 | | OI criterion, center, and sex Birth weight, center, OI entry criterion strata, sex
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | Control Birth weight >1000g, F/U Cohort | 48 | 20 (42) | P-value: 0.39 | RR: 0.80 (0.48-1.33) | OI criterion, center, and sex Birth weight, center, OI entry criterion strata, sex
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | iNO Tx, Birth weight >1000g | 48 | 16 (33) | P-value: 0.39 | | OI criterion, center, and sex Birth weight, center, OI entry criterion strata, sex
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | Control Placebo, Birth weight 401-750grams | 99 / 400 (analysis cohort) | 61 (62) | | | Center, and sex
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | iNO tx, Birth weight 401-750grams | 94 / 400 (for analysis cohort) | 75 / 93 (81) | | | Center, and sex
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | Control Placebo, Birth weight 751-1000grams | 53 | 28 (53) | | | Center, and sex
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | iNO tx, Birth weight 751-1000grams) | 58 / 400 (analysis cohort) | 36 (62) | | | Center, and sex
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | Control Placebo, Birth weight 1001-1500 grams) | 48 / 400 (analysis group) | 20 (42) | | | Center, and sex
Hintz SR, 2007^8^ | Death or NDI | 18-22 months | iNO tx. Birth weight 1001-1500grams) | 48 / 400 (analysis group) | 16 (33) | | | Center, and sex
Watson, 2009^12^ | Death or NDI | 1 year corrected age | Control birth weight 500-749 g | 187 | 96 (51.3) | P-value: 0.57
Watson, 2009^12^ | Death or NDI | 1 year corrected age | iNO birth weight 500-749 g | 188 | 102 (54.3) | P-value: 0.57
Watson, 2009^12^ | Death or NDI | 1 year corrected age | Control birth weight 750-999 g | 133 | 59 (44.4) | P-value: 0.04
Watson, 2009^12^ | Death or NDI | 1 year corrected age | iNO birth weight 750-999 g) | 140 | 45 (32.1) | P-value: 0.04
Watson, 2009^12^ | Death or NDI | 1 year corrected age | Control birth weight 1000-1250 g | 64 | 16 (25) | P-value: 0.63
Watson, 2009^12^ | Death or NDI | 1 year corrected age | iNO birth weight 1000-1250 g | 59 | 17 (28.8) | P-value: 0.63
Watson, 2009^12^ | Death or NDI | 1 year corrected age | Control | 384 | 171 (44.5) | P-value: 0.55
Watson, 2009^12^ | Death or NDI | 1 year corrected age | iNO | 387 | 164 (42.4) | P-value: 0.55
Watson, 2009^12^ | Death or NDI | 1 year corrected age | Control | 384 | 175 (45.6) | P-value: 0.65
Watson, 2009^12^ | Death or NDI | 1 year corrected age | iNO | 387 | 170 (43.9) | P-value: 0.65
Watson, 2009^12^ | Death or NDI | 1 year corrected age | Control birth weight 500-749 g | 187 | 98 (52.4) | P-value: 0.38
Watson, 2009^12^ | Death or NDI | 1 year corrected age | iNO birth weight 500-749 g | 188 | 107 (56.9) | P-value: 0.38
Watson, 2009^12^ | Death or NDI | 1 year corrected age | Control birth weight 750-999 g | 133 | 60 (45.1) | P-value: 0.04
Watson, 2009^12^ | Death or NDI | 1 year corrected age | iNO birth weight 750-999 g | 140 | 46 (32.9) | P-value: 0.04
Watson, 2009^12^ | Death or NDI | 1 year corrected age | Control birth weight 1000-1250 g | 64 | 17 (26.6) | P-value: 0.78
Watson, 2009^12^ | Death or NDI | 1 year corrected age | iNO birth weight 1000-1250 g) | 59 | 17 (28.8) | P-value: 0.78
Uga, 2004^13^ | Survival | 28 days | Control | 5 | 10 (50)
Uga, 2004^13^ | Survival | 28 days | iNO | 8 | 8 (100)
Field, 2005^2^ | Severe Disability | 1 year | Control | 53 | 2 (4)
Field, 2005^2^ | Severe Disability | 1 year | iNO | 55 | 7 (13)
Yadav, 1999^10^ | Survival to Discharge | 27 weeks | Responders | 15 | 26
Yadav, 1999^10^ | Survival to Discharge | 27 weeks | Non-responders | 1 | 15
Hintz, 2007^8^ | Death or Moderate to severe CP | 18-22 months | Control | | 109 (54) | P = 0.07 RR = 1.17 (0.99-1.38)
Hintz, 2007^8^ | Death or Moderate to severe CP | 18-22 months | iNO | 199 | 127 (64) | P = 0.07 RR = 1.17 (0.99-1.38)
Watson, 2009^12^ | Death/Oxygen/NDI | 1 year | Control | | 175 (45.6) | P = 0.65
Watson, 2009^12^ | Death/Oxygen/NDI | 1 year | iNO | | 170 (43.9) | P = 0.65
Watson, 2009^12^ | Death/Oxygen/NDI | BW: 500-749g | Control | | 98 (52.4)
Watson, 2009^12^ | Death/Oxygen/NDI | BW: 500-749g | iNO | | 107 (56.9)
Watson, 2009^12^ | Death/Oxygen/NDI | BW: 750-999g | Control | | 60 (45.1)
Watson, 2009^12^ | Death/Oxygen/NDI | BW: 750-999g | iNO | | 46 (32.9)
Watson, 2009^12^ | Death/Oxygen/NDI | BW: 1000-1250g | Control | | 17 (26.6)
Watson, 2009^12^ | Death/Oxygen/NDI | BW: 1000-1250g | iNO | | 17 (28.8)

BPD: Bronchopulmonary Dysplasia; BPD: Bronchopulmonary Dysplasia; BSID: Bayley scale of infant development; BW: Birth weight; CI: Confidence Interval; CP: Cerebral palsy; DQ: Developmental quotient; EDC: Estimated date of confinement; F/U: Follow: up; GEE: Generalized estimated equations; HFOV: High-frequency oscillatory ventilation; HFV: High-frequency ventilation; HRF: Hypoxemic respiratory failure; ICH: Intracranial Hemorrhage; iNO: Inhaled nitric oxide; IQR: Inter-quartile range; IVH: Intraventricular hemorrhage ; MDI: Mental developmental scale; NDI: Neurodevelopmental impairment; NICU: Neonatal intensive care unit; NS: Not significant; OI: Oxygenation index; PMA: Postmenstrual age; PVL: Periventricular leukomalacia; RR: Relative risk; SD: Standard deviation; tx: treatment;

Evidence Table 17 All outcomes addressed in the KQ5 subgroups including death, BPD, and NDI

Author, Year | Outcome | Time of outcome measure | Study Arm | N (number of participants measured) | Participants with Outcome— n (%) | Relative Effect (95% CI) | Adjusted Relative Effect (95% CI) | Adjustments | Duration | Difference in Duration (p-value)
Ballard, 2006^1^ | BPD | 36 weeks PMA | Control | 288 | 164 (56.9)
Ballard, 2006^1^ | BPD | 36 weeks PMA | iNO | 294 | 149 (50.7)
Dani, 2006^2^ | BPD | 36 weeks PMA | Control | 20 | 12 (60) | P-value: 0.067 | | | Mean: 69.4 SD: 30.2 | 0.054
Dani, 2006^2^ | BPD | 36 weeks PMA | iNO | 20 | 6 (30) | | | | Mean: 47.3 SD: 39.4 | 0.054
Dani, 2006^2^ | BPD | 36 weeks PMA | Nonresponders | 6 | | | | | Mean: 19.8 SD: 11.5 | 0.084
Dani, 2006^2^ | BPD | 36 weeks PMA | Responders | 14 | | | | | Mean: 48.6 SD: 37.3 | 0.084
Field, 2005^3^ | BPD | 36 weeks PMA | Control | 49 | 15 (28) | | | | Mean: 6 IQR:1.0-17.0
Field, 2005^3^ | BPD | 36 weeks PMA | iNO | 50 | 26 (47) | | | | Mean: 15 IQR:2-71
Franco-Belgium Collabor ative NO Trial Group, 1999^4^ | BPD | during hospitalization | Control | 29 | 8 (29) | p-value: NS | | | Median: 23 IQR:41 | 0.38
Franco-Belgium Collabor ative NO Trial Group, 1999^4^ | BPD | during hospitalization | iNO | 29 | 7 (24) | p-value: NS OR: 0.95 (0.44–2.04) | | | Median: 14 IQR:43 | 0.38
Kinsella, 1999^5^ | BPD | 36 weeks PMA | Control | 15 | 12 (80) | p-value: 0.3 RR: 0.75(0.5-1.13)
Kinsella, 1999^5^ | BPD | 36 weeks PMA | iNO | 25 | 15 (60) | p-value: 0.3 RR: 0.75(0.5-1.13)
Kinsella, 2006^6^ | BPD | 36 weeks BDP at 36 weeks PMA | Control | 309 | 210 (68) | P-value: 0.43 | RR:0.96 (0.86–1.09) | randomization strata, study sight
Kinsella, 2006^6^ | BPD | 36 weeks BDP at 36 weeks PMA | iNO | 326 | 212 (65) | P-value: 0.43 | RR:0.96 (0.86–1.09)
Mercier, 2010^7^ | BPD | 36 weeks PMA | Control | 358 | 96 (27)
Mercier, 2010^7^ | BPD | 36 weeks PMA | iNO | 339 | 81(24)
Schreiber, 2003^8^ | BPD | 36 weeks PMA | Control | 102 | 42 (53.2) | | P-value: 0.07 RR: 0.74 (0.53–1.03) | type of ventilation
Schreiber, 2003^8^ | BPD | 36 weeks PMA | iNO | 105 | 35 (39.3)
Su, 2008^9^ | BPD | 36 weeks PMA | Control | 33 | 11 (33.3)
Su, 2008^9^ | BPD | 36 weeks PMA | iNO | 32 | 10 (31.3)
Subhedar, 1997^10^ | BPD | 36 weeks PMA | Control dexamethasone and standard of care | 22 | 14 (64)
Subhedar, 1997^10^ | BPD | 36 weeks PMA | Groups 1&3; iNO + iNO and dexamethasone | 20 | 10 (50) | RR: 0.79(0.44-1.33)
Subhedar, 1997^10^ | BPD | 36 weeks PMA | Dexamethasone alone AND dex + iNO | 21 | 11 (52)
Subhedar, 1997^10^ | BPD | 36 weeks PMA | iNO AND standard of care | 21 | 13 (62) | RR: 0.85(0.48-1.44)
Van Meurs, 2007^11^ | BPD | 36 weeks PMA | Control | 11 | 5 (45) | p-value: 0.66 RR: 0.66(0.21-2.08) | p-value: 0.21 RR: 0.40 (0.09-1.71) | OI stratum | Mean: 32 SD:23 | 0.45
Van Meurs, 2007^11^ | BPD | 36 weeks PMA | iNO | 10 | 3 (30) | p-value: 0.66 RR: 0.66(0.21-2.08) | p-value: 0.21 RR: 0.40 (0.09-1.71) | | Mean: 23.8 SD: 24.4 | 0.45
Van Meurs, 2007^12^ | BPD | 36 weeks PMA | Control | 127 | 86 (68) | P-value: 0.26 | RR: 0.90 (0.75–1.08)
Van Meurs, 2007^12^ | BPD | 36 weeks PMA | iNO | 109 | 65 (60) | P-value: 0.26 | RR: 0.90 (0.75–1.08)
Ballard, 2006^1^ | BPD | 40 weeks PMA | Control | 288 | 84 (29.2)
Ballard, 2006^1^ | BPD | 40 weeks PMA | iNO | 294 | 66 (22.4)
Ballard, 2006^1^ | BPD | 40 weeks PMA | Control | 288 | 35 (12.2)
Ballard, 2006^1^ | BPD | 40 weeks PMA | iNO | 294 | 27 (9.2)
Field, 2005^3^ | BPD | At term (EDC) | Control | 53 | 12 (23) | | | | Median: 81 IQR:14-100
Field, 2005^3^ | BPD | At term (EDC) | iNO | 55 | 16 (29) | | | | Median: 59 IQR:30-78
Field, 2005^3^ | BPD | 1 year corrected age | Control | 18 survivors | 1 (6)
Field, 2005^3^ | BPD | 1 year corrected age | iNO | 20 survivors | 3 (15)
Franco-Belgium Collabor ative NO Trial Group, 1999^4^ | BPD | 28 days | Control | 29 | 14 (48) | p-value: NS
Franco-Belgium Collabor ative NO Trial Group, 1999^4^ | BPD | 28 days | iNO | 29 | 13 (45)
Hamon, 2005^13^ | BPD | 28 days | Control Hypoxemic Respiratory Failure, no iNO | 29 | 15 (55.6)
Hamon, 2005^13^ | BPD | 28 days | iNO treated Hypoxemic Respiratory Failure | 22 | 8 (36.4)
Kinsella,1999^5^ | BPD | Hospital discharge | Control | 15 | 12 (80) | p-value: 0.1
Kinsella,1999^5^ | BPD | Hospital discharge | Control | 15 | 12 (80) | RR: 0.65 (0.41-1.02)
Kinsella,1999^5^ | BPD | Hospital discharge | iNO | 25 | 13 (54) | p-value: 0.1 1.02)
Kinsella,1999^5^ | BPD | Hospital discharge | iNO | 25 | 13 (54) | RR: 0.65(0.41-
Van Meurs,2005^12^ | BPD | Physiologic BPD as per Walsh criteria | Control | 115 | 69 (60) | P-value: 0.17 | RR: 0.87 (0.68–1.10) | center, birth-weight group, and oxygenation-index entry stratum
Van Meurs,2005^12^ | BPD | Physiologic BPD as per Walsh criteria | iNO | 100 | 50 (50) | P-value: 0.17 | RR: 0.87 (0.68–1.10)
| | Physiologic BPD as per Walsh criteria | | | | OR (95% CI) | Adjusted OR (95% CI)
Ballard, 2006^1^ | Death | 36 weeks PMA | Control | 288 | 18 (6.3)
Ballard, 2006^1^ | Death | 36 weeks PMA | iNO | 294 | 16 (5.4)
Ballard, 2006^1^ | Death | 40 weeks PMA | Control | 288 | 19 (6.6)
Ballard, 2006^1^ | Death | 40 weeks PMA | iNO | 294 | 19 (6.5)
Ballard, 2006^1^ | Death | 44 wks PMA | Control | 288 | 20 (6.9)
Ballard, 2006^1^ | Death | 44 wks PMA | iNO | 294 | 20 (6.8)
Ballard, 2006^1^ | Death | 36 weeks PMA | Control 7-14 days age at study entry | 115 | 13 (11.3)
Ballard, 2006^1^ | Death | 36 weeks PMA | 7-14 days age at study entry | 112 | 12 (10.7)
Ballard, 2006^1^ | Death | 36 weeks PMA | Control 15-21 days age at study entry | 173 | 10 (5.8)
Ballard, 2006^1^ | Death | 36 weeks PMA | iNO 15-21 days age at study entry | 182 | 12 (6.6)
Banks, 1999^14^ | Death | 3-24 months from enrollment | iNO | 16 | 7 (44)
Bennett, 2001^15^ | Death | 30 months corrected age | Control | 22 | 7 (32) | P-value: 0.13 RR: 1.65 (0.87–3.3)
Bennett, 2001^15^ | Death | 30 months corrected age | iNO | 20 | 10 (50) | P-value: 0.13 RR: 1.65 (0.87–3.3)
Bennett, 2001^15^ | Death | 24.9 +/- 7.9 months corrected age | iNO | 105 | 89 (85) | P-value: 0.13 RR: 1.65 (0.87–3.3)
Dani, 2002^6^ | Death | NICU | Control | 20 | 6(30) | | P-value: 0.494 | birth weight
Dani, 2002^6^ | Death | NICU | iNO | 20 | 4 (20) | | P-value: 0.494
Dani, 2002^6^ | Death | NICU | Nonresponders | 6 | 4 (66) | P-value: 0.078
Dani, 2002^6^ | Death | NICU | Responders | 14 | 3 (21) | P-value: 0.078
Field, 2005^3^ | Death | 1 year | Control | 53 | 34 (64)
Field, 2005^3^ | Death | 1 year | iNO | 55 | 30 (55)
Franco-Belgium Collaborative NO Trial Group, 1999^4^ | Death | in NICU | Control | 45 | 16 (35) | P-value: Not significant
Franco-Belgium Collaborative NO Trial Group, 1999^4^ | Death | in NICU | iNO | 40 | 11 (27) | P-value: Not significant
Hascoet, 2005^16^ | Death | 7 days of life | Control with Hypoxemic Respiratory Failure | 84 | 14 (17) | P-value: 0.58 | 1
Hascoet, 2005^16^ | Death | 7 days of life | iNO with Hypoxemic Respiratory Failure | 61 | 8 (13) | P-value: 0.58 | 1
Hascoet, 2005^16^ | Death | 28 days of life | Control with Hypoxemic Respiratory Failure | 84 | 26 (31) | P-value: Not significant
Hascoet, 2005^16^ | Death | 28 days of life | iNO with Hypoxemic Respiratory Failure | 61 | 25 (41) | P-value: Not significant
Hintz SR, 2007^17^ | Death | 18-22 months | Control | 210 | 98 (47) | | P-value: 0.27 | birth weight category, OI strata
Hintz SR, 2007^17^ | Death | 18-22 months | iNO | 210 | 109 (52) | | P-value: 0.27
Huddy, 2008^18^ | Death | 4-5 years, median 4.52 (IQR 0.9) | Control | 19 | 0 (0)
Huddy, 2008^18^ | Death | 4-5 years, median 4.63, IQR 0.84) | iNO | 25 | 1 (4)
Kinsella , 2006^6^ | Death | 36 wks PMA | Control | 392 | 98 (25) | | P-value: 0.08 RR: 0.79 (0.61-1.03) | randomization strata, study sight
Kinsella , 2006^6^ | Death | 36 wks PMA | iNO | 394 | 78 (19.8)
Kinsella, 1999^5^ | Death | Discharge | Control | 32 | 17 (53) | P-value: 0.65 RR: 1.11(0.7-1.8)
Kinsella, 1999^5^ | Death | Discharge | iNO | 48 | 23 (48) | P-value: 0.65 RR: 1.11(0.7-1.8)
Mercier, 2010^7^ | Death | | Control | 401 | 42 (10.5)
Mercier, 2010^7^ | Death | | iNO | 399 | 56 (14)
Schreiber, 2003^8^ | Death | NICU | Control | 102 | 23 (22.5) | P-value: 0.18 RR: 0.68 (0.38-1.20) | RR: 0.68 (0.38-1.20) | type of ventilation
Schreiber, 2003^8^ | Death | NICU | iNO | 105 | 16 (15.2)
Srisuparp, 2002^19^ | Death | 7 days | Control | 22 | 2 (11.1) | P-value: 1
Srisuparp, 2002^19^ | Death | 7 days | iNO | 16 | 2 (12.5) | P-value: 1
Su, 2008^9^ | Death | During Study (9 death within 96 hours) | Control | 33 | 10 (30.3)
Su, 2008^9^ | Death | During Study (9 death within 96 hours) | iNO | 32 | 6 (18.8)
Subhedar, 1997^10^ | Death | 36 wks PMA | Control dexamethasone and standard of care | 22 | 7 (32) | RR: 1.57(0.76-3.38)
Subhedar, 1997^10^ | Death | 36 wks PMA | Groups 1&3; iNO + iNO and dexamethasone | 20 | 10 (50) | RR: 1.57(0.76-3.38)
Subhedar, 1997^10^ | Death | 36 wks PMA | Dexamethasone alone AND dex + iNO | 21 | 9 (43) | RR: 1.13 (0.54-2.36)
Subhedar, 1997^10^ | Death | 36 wks PMA | iNO AND standard of care | 21 | 8 (38) | RR: 1.13 (0.54-2.36)
Van Meurs, 2005^12^ | Death | death before discharge to home or within 365 | Control | 208 | 93 (45) | | P-value: 0. 11 RR:1.16 (0.96-1.39) | Birthweight study center, Oxygen ation index
| Death | | iNO | 210 | 109 (52)
Van Meurs, 2007^11^ | Death | Death before discharge to home or within 365 | Control | 15 | 4 (27) | P-value: 0.7 RR: 1.34 (0.45-4.0) | p-value: 0.65 RR: 1.26 (0.47-3.41) | OI Stratum
Van Meurs, 2007^11^ | Death | Death before discharge to home or within 365 | iNO | 14 | 5 (36)
Walsh, 2010^20^ | Death | 2 years | Control | 288 | 23 (8) | RR: 1.02 (0.59-1.77)
Walsh, 2010^20^ | Death | 2 years | iNO | 294 | 24 (8.2) | RR: 1.02 (0.59-1.77)
Watson, 2009^21^ | Death | 1 year corrected age | Control | 384 | 98 (25.5) | P-value: 0.12
Watson, 2009^21^ | Death | 1 year corrected age | iNO | 385 | 80 (20.8) | P-value: 0.12
Ballard, 2006^1^ | Death or BPD | 36 weeks PMA | Control | 288 | 182 (63.2)
Ballard, 2006^1^ | Death or BPD | 36 weeks PMA | iNO | 294 | 165 (56.1)
Dani, 2006^2^ | Death or BPD | NICU | Control | 20 | 18 (90) | P-value: 0.016 OR: 0.111 (0.02-0.610)
Dani, 2006^2^ | Death or BPD | NICU | iNO | 20 | 10 (50) | P-value: 0.016 OR: 0.111 (0.02-0.610)
Dani, 2006^2^ | Death or BPD | NICU | Nonresponders | 6 | 6 (100) | P-value: 0.035
Dani, 2006^2^ | Death or BPD | NICU | Responders | 14 | 10 (71) | P-value: 0.035
Field, 2005^3^ | Death or BPD | 36 weeks PMA | Control | 53 | 48 (91)
Field, 2005^3^ | Death or BPD | 36 weeks PMA | iNO | 55 | 49 (89)
Field, 2005^3^ | Death or BPD | 36 weeks PMA | Control trial entry <= 3 days | 37 | 32 (86) | | RR: 0.98(0.87-1.11)
Field, 2005^3^ | Death or BPD | 36 weeks PMA | iNO trial entry <= 3 days) | 38 | 32 (84) | | RR: 0.98(0.87-1.11)
Field, 2005^3^ | Death or BPD | 36 weeks PMA | Control trial entry > 3 days | 16 | 16 (100)
Field, 2005^3^ | Death or BPD | 36 weeks PMA | iNO trial entry > 3 days | 17 | 17 (100)
Franco-Belgium Collabor ative NO Trial Group, 1999^4^ | Death or BPD | in NICU | Control | 45 | 24 (53)
Franco-Belgium Collabor ative NO Trial Group, 1999^4^ | Death or BPD | in NICU | iNO | 40 | 18 (45)
Kinsella, 1999^5^ | Death or BPD | Discharge | Control | 32 | 29 (91) | P-value: 0. 14 RR: 0.85(0.7-1.03)
Kinsella, 1999^5^ | Death or BPD | Discharge | iNO | 48 | 37 (77) | P-value: 0. 14 RR: 0.85(0.7-1.03)
Kinsella, 2006^6^ | Death or BPD | 36 wks PMA | Control | 392 | 295 (75.3) | | P-value: 0.24 RR: 0.95 (0.87-1.03) | Study sight, randomization strata
Kinsella, 2006^6^ | Death or BPD | 36 wks PMA | iNO | 394 | 282 (71.6) | | P-value: 0.24 RR: 0.95 (0.87-1.03)
Schreiber, 2003^8^ | Death or BPD | NICU | Control | 102 | 65 (63.7) | P-value: 0.03 RR: 0.76 (0.60-0.97) | RR: 0.77 (0.60-0.98) | type of ventilation
Schreiber, 2003^8^ | Death or BPD | NICU | iNO | 105 | 51 (48.6) | P-value: 0.03 RR: 0.76 (0.60-0.97) | RR: 0.77 (0.60-0.98)
Subhedar, 1997^10^ | Death or BPD | 36 weeks PMA | Control dexamethasone and standard of care | 22 | 21 (95) | RR: 1.05(0.84-1.25)
Subhedar, 1997^10^ | Death or BPD | 36 weeks PMA | Groups 1&3; iNO + iNO and dexamethasone | 20 | 20 (100) | RR: 1.05(0.84-1.25)
Subhedar, 1997^10^ | Death or BPD | 36 weeks PMA | Dexamethasone alone AND dex + iNO | 21 | 20 (95) | RR: 0.95 (0.79-1.18)
Subhedar, 1997^10^ | Death or BPD | 36 weeks PMA | iNO AND standard of care | 21 | 21 (100) | RR: 0.95 (0.79-1.18)
Van Meurs, 2007^11^ | Death or BPD | Death before discharge to home or within 365 | Control | 15 | 9 (60) | P-value: 0.87 RR: 0.83 (0.43-1.62) | p-value: 0.5 RR: 0.80 (0.43-1.48) | OI Stratum
Van Meurs, 2007^11^ | Death or BPD | Death before discharge to home or within 365 | iNO | 14 | 7 (50) | P-value: 0.87 RR: 0.83 (0.43-1.62) | p-value: 0.5 RR: 0.80 (0.43-1.48)
Van Meurs, 2005^12^ | Death or BPD | before discharge to home or within 365 days among hospitalized infants | Control | 208 | 170 (82) | | P-value: 0.52 RR: 0.97 (0.86-1.06) | birth weight, study site, Oxygenation index
Van Meurs, 2005^12^ | Death or BPD | before discharge to home or within 365 days among hospitalized infants | iNO | 210 | 167 (80) | | P-value: 0.52 RR: 0.97 (0.86-1.06)
Watson, 2009^21^ | Death or BPD | 1 Year corrected | Control | 385 | 110 (28.7) | P-value: 0.29
Watson, 2009^21^ | Death or BPD | 1 Year corrected | iNO | 384 | 97 (25.3) | P-value: 0.29
Hintz SR, 2007^17^ | Death or NDI, Death or moderate to severe CP | 18-22 months | Control | 200 | 109 (54) | P-value: 0.07 RR:1.17 (0.99-1.38) | P-value: 0.07 RR: Model #1: 1.15 (0.99-1.34) | Model #1:BWt, center, OI entry criterion strata, sex
Hintz SR, 2007^17^ | Death or NDI, Death or moderate to severe CP | 18-22 months | iNO Follow-Up group | 199 | 127 (64) | P-value: 0.07 RR:1.17 (0.99-1.38) | P-value: 0.07 RR: Model #1: 1.15 (0.99-1.34)
Hintz SR, 2007^17^ | Death or NDI Death or NDI:any of the following: mod-severe CP, blind, deaf, MDI<70 or PDI<70 | 18-22 months | Control | 200 | 146 (73) | P-value: 0.32 RR:1.07 (0.95-1.19) | P-value: 0.3 RR: Model #1: 1.06 (0.95-1.17) | Model #1: BWt, center, OI entry criterion strata, sex
Hintz SR, 2007^17^ | Death or NDI Death or NDI:any of the following: mod-severe CP, blind, deaf, MDI<70 or PDI<70 | 18-22 months | iNO Follow-Up group | 198 | 154 (78) | P-value: 0.32 RR:1.07 (0.95-1.19) | P-value: 0.3 RR: Model #1: 1.06 (0.95-1.17)
Hintz SR, 2007^17^ | Death or NDI Death or NDI:any of the following: mod-severe CP, blind, deaf, MDI<70 or PDI<70 | 18-22 months | Control HFV, F/U cohort | 119 | 93 (78) | P-value: 0.91 | RR: 1.01 (0.88-1.15) | OI criterion, center, and sex Birth weight, center, OI entry criterion strata, sex
Hintz SR, 2007^17^ | Death or NDI Death or NDI:any of the following: mod-severe CP, blind, deaf, MDI<70 or PDI<70 | 18-22 months | iNO tx, HFV | 115 | 90 (78) | P-value: 0.91 | RR: 1.01 (0.88-1.15)
Hintz SR, 2007^17^ | Death or NDI Death or NDI:any of the following: mod-severe CP, blind, deaf, MDI<70 or PDI<70 | 18-22 months | Control Convention al vent, F/U cohort | 81 | 53 (65) | P-value: 0.12 | RR: 1.15(0.97-1.36) | OI criterion, center, and sex Birth weight, center, OI entry criterion strata, sex
Hintz SR, 2007^17^ | Death or NDI Death or NDI:any of the following: mod-severe CP, blind, deaf, MDI<70 or PDI<70 | 18-22 months | iNO tx, Convention al Vent | 83 | 64 (77) | P-value: 0.12 | RR: 1.15(0.97-1.36)
Field, 2005^3^ | Death or Severe Disability | 1 year corrected | Control trial entry <= 3 days | 37 | 24 (65) | | RR: 0.99(0.76-1.28) | diagnosis, OI severity
Field, 2005^3^ | Death or Severe Disability | 1 year corrected | iNO trial entry <= 3 days | 38 | 25 (66) | | RR: 0.99(0.76-1.28)
Field, 2005^3^ | Death or Severe Disability | 1 year corrected | Control trial entry > 3 days | 16 | 12 (75) | | | diagnosis, OI severity
Field, 2005^3^ | Death or Severe Disability | 1 year corrected | iNO trial entry > 3 days | 17 | 12 (71)
Bennett, 2001^15^ | Survival | 30 months corrected age | Control | 22 | 14 (63.6) | P-value: 0.13 RR: 1.65(0.87-3.3)
Bennett, 2001^15^ | Survival | 30 months corrected age | iNO | 20 | 8(40) | P-value: 0.13 RR: 1.65(0.87-3.3)
Hamon, 2005^13^ | Survival | 28 days | Control Hypoxemic Respiratory Failure, no iNO | 39 | 27 (69.3)
Hamon, 2005^13^ | Survival | 28 days | iNO treated Hypoxemic Respiratory Failure | 37 | 22 (59.5)
Mestan, 2005^22^ | Survival | 25.2+/-8.4 months corrected age | Control | 102 | 79 (78)
Schreiber, 2003^8^ | Survival | Survived NICU | Control | 102 | 79 (77.5)
Schreiber, 2003^8^ | Survival | Survived NICU | iNO | 105 | 89 (84.8)
Ballard, 2006^1^ | Survival without BPD | 36 weeks PMA | Control | 288 | 105 (36.5) | p-value:0.04 RR: 1.26 (1.02-1.55) | RR: 1.45 (1.03-2.04) | cluster (multiples) using GEE; from the letter to the editor correction
Ballard, 2006^1^ | Survival without BPD | 36 weeks PMA | iNO | 294 | 129 (43.9)
Ballard, 2006^1^ | Survival without BPD | 36 weeks PMA | Control 7-14 days age at study entry | 115 | 31 (27) | RR: 1.91 (1.31-2.78)
Ballard, 2006^1^ | Survival without BPD | 36 weeks PMA | iNO 7-14 days age at study entry | 112 | 55 (49.1)
Ballard, 2006^1^ | Survival without BPD | 36 weeks PMA | Control 15-21 days age at study entry | 173 | 74 (42.8) | RR: 0.99 (0.77-1.28)
Ballard, 2006^1^ | Survival without BPD | 36 weeks PMA | iNO 15-21 days age at study entry | 182 | 74 (40.7)
Hamon, 2005^13^ | Survival without BPD | 28 days | Control | 39 | 12 (31)
Hamon, 2005^13^ | Survival without BPD | 28 days | iNO | 37 | 14 (38)
Bennett, 2001^15^ | Severe neurodisability - one or more of: moderate or severe developmental delay; CP; sensorine ural impairment (hearing loss requiring hearing aids and blindness) | 30 months corrected age | Control | 14 | 5 (36) | P-value: 0.12
Bennett, 2001^15^ | Severe neurodisability - one or more of: moderate or severe developmental delay; CP; sensorine ural impairment (hearing loss requiring hearing aids and blindness) | 30 months corrected age | iNO | 7 | 0 (0) | P-value: 0.12
Field, 2005^3^ | Severe disability defined as no /little head control or inability to sit unsupport ed or no/minimal response to visual stim (equivalent to DQ <50 age adjusted) | 1 year corrected age | Control | 18 | 2 (11)
Field, 2005^3^ | Severe disability defined as no /little head control or inability to sit unsupport ed or no/minimal response to visual stim (equivalent to DQ <50 age adjusted) | 1 year corrected age | iNO | 25 | 7 (28)
Hintz SR, 2007^17^ | NDI: any of the following: mod-severe CP, blind, deaf, MDI<70 or PDI<70 | 18-22 months | Control | 102 | 48 (47) | P-value:0.74 RR: 1.07(0.80 - 1.44)
Hintz SR, 2007^17^ | NDI: any of the following: mod-severe CP, blind, deaf, MDI<70 or PDI<70 | 18-22 months | iNO | 89 | 45 (51) | P-value:0.74 RR: 1.07(0.80 - 1.44)
Huddy, 2008^18^ | Moderate or severe cognitive disability (GCAS<7 0) | 4-5 yrs, median 4.52 (IQR 0.9) | Control | 16 | 6(37.5)
Huddy, 2008^18^ | Moderate or severe cognitive disability (GCAS<7 0) | 4-5 yrs, median 4.63, IQR 0.84) | iNO | 22 | 6(27.3)
Huddy, 2008^18^ | Moderate / Severe CP | 4-5 years | Control | 16 | 2(12.5)
Huddy, 2008^18^ | Moderate / Severe CP | 4-5 years | iNO | 22 | 3(13.6)
Mestan, 2005^22^ | Abnormal neurodeve lopmental outcome (any Disability or any BSID II score <70) | 25.2+/-8.4 months corrected age 24.9+/- 7.9 months corrected age | Control | 68 | 31 (46) | P-value:0.01 RR: 0.53 (0.33-0.87)
Mestan, 2005^22^ | Abnormal neurodeve lopmental outcome (any Disability or any BSID II score <70) | 25.2+/-8.4 months corrected age 24.9+/- 7.9 months corrected age | iNO | 70 | 17 (24) | P-value:0.01 RR: 0.53 (0.33-0.87)
Van Meurs 2007^11^ | NDI = any one of the following: moderate to severe CP, blind, deaf, MDI <70, or PDI <70 | 18 to 22 months | Control | 8 | 2 (25)
Van Meurs 2007^11^ | NDI = any one of the following: moderate to severe CP, blind, deaf, MDI <70, or PDI <70 | 18 to 22 months | iNO | 9 | 1 (11)
Walsh, 2010^20^ | NDI in subset with complete evaluations | 2 years | Control | 212 | (51) | RR:0.93 (0.76-1.14)
Walsh, 2010^20^ | NDI in subset with complete evaluations | 2 years | iNO | 207 | (48) | RR:0.93 (0.76-1.14)
Walsh, 2010^20^ | Neurodev elopmental Impairment (NDI = MDI<70, PDI<70, unable to crawl or walk (GMFCS> =2), bilateral blindness, or bilateral deafness requiring amplification). | 2 years | Control | 234 | 114 (49) | RR: 0.92 (0.75-1.12)
Walsh, 2010^20^ | Neurodev elopmental Impairment (NDI = MDI<70, PDI<70, unable to crawl or walk (GMFCS> =2), bilateral blindness, or bilateral deafness requiring amplification). | 2 years | iNO | 243 | 109 (44.8) | RR: 0.92 (0.75-1.12)
Walsh, 2010^20^ | Moderate / Severe CP | 2 years | Control | 234 | 12 (5.1) | RR: 1.23 (0.59-2.55)
Walsh, 2010^20^ | Moderate / Severe CP | 2 years | iNO | 243 | 12 (4.9) | RR: 1.23 (0.59-2.55)
Watson, 2009^21^ | NDI (CP, severe hearing loss, MDI or PDI< 70,or blindness) | 1 year corrected age | Control | 218 | 73 (33.5) | P-value: 0.66
Watson, 2009^21^ | NDI (CP, severe hearing loss, MDI or PDI< 70,or blindness) | 1 year corrected age | iNO | 237 | 84 (35.4) | P-value: 0.66
Van Meurs, 2007^11^ | Moderate / Severe CP | 18 to 22 months | Control | 8 | 0 (0)
Van Meurs, 2007^11^ | Moderate / Severe CP | 18 to 22 months | iNO | 9 | 0 (0)

BPD: Bronchopulmonary Dysplasia; BSID: Bayley scale of infant devleopment; BW: Birth weight; CI: Confidence Interval; CP: Cerebral palsy; DQ: Developmental quotient; EDC: Estimated date of confinement; F/U: Follow: up; HFOV: High-frequency oscillatory ventilation; HFV: High-frequency ventilation; HRF: Hypoxemic respiratory failure; iNO: Inhaled nitric oxide; IQR: Inter-quartile range; IVH: Intraventricular hemorrhage ; MDI: Mental developmental scale; NDI: Neurodevelopmental impairment; NICU: Neonatal intensive care unit; NS: Not significant; OI: Oxygenation index; OR: Odds ratio; PDI: Psychomotor Development Index; PMA: Post-menstrual age; PVL: Periventricular leukomalacia; RR: Relative risk; SD: Standard Deviation; tx: Treatment;

## Appendix E References

### Reference List for Evidence Table 1

1 Ballard RA, Truog WE, Cnaan A, et al. Inhaled nitric oxide in preterm infants undergoing mechanical ventilation. New Engl. J. Med. 2006;355(4):343-53. [pmid: 16870913].
2 Hibbs AM, Walsh MC, Martin RJ, et al. One Year Respiratory Outcomes of the Preterm Infants Enrolled in the NO CLD Trial of Inhaled Nitric Oxide (iNO). N/A. 2007.
3 Walsh MC, Hibbs AM, Martin CR, et al. Two-year neurodevelopmental outcomes of ventilated preterm infants treated with inhaled nitric oxide. J Pediatr. 2010;156(4):556-61.e1. [pmid: 20138299].
4 Dani C, Bertini G, Pezzati M, Filippi L, Cecchi A, Rubaltelli FF. Inhaled nitric oxide in very preterm infants with severe respiratory distress syndrome. Acta Paediatr. 2006;95(9):1116-23. [pmid: 16938760].
5 Franco-Belgium Collaborative NO Trial Group. Early compared with delayed inhaled nitric oxide in moderately hypoxaemic neonates with respiratory failure: a randomised controlled trial. The Franco-Belgium Collaborative NO Trial Group. Lancet. 1999;354(9184):1066-71. [pmid: 10509497].
6 Field D, Elbourne D, Truesdale A, et al. Neonatal Ventilation With Inhaled Nitric Oxide Versus Ventilatory Support Without Inhaled Nitric Oxide for Preterm Infants With Severe Respiratory Failure: the INNOVO multicentre randomised controlled trial (ISRCTN 17821339). Pediatrics. 2005;115(4):926-36. [pmid: 15805366].
7 Huddy CL, Bennett CC, Hardy P, et al. The INNOVO multicentre randomised controlled trial: neonatal ventilation with inhaled nitric oxide versus ventilatory support without nitric oxide for severe respiratory failure in preterm infants: follow up at 4-5 years. Arch Dis Child Fetal Neonatal Ed. 2008;93(6):F430-5. [pmid: 18375612].
8 Hascoet JM, Fresson J, Claris O, et al. The safety and efficacy of nitric oxide therapy in premature infants. J. Pediatr. 2005;146(3):318-23. [pmid: 15756211].
9 Hamon I, Fresson J, Nicolas MB, Buchweiller MC, Franck P, Hascoet JM. Early inhaled nitric oxide improves oxidative balance in very preterm infants. Pediatr Res. 2005;57(5 Pt 1):637-43. [pmid: 15746261].
10 Kinsella JP, Walsh WF, Bose CL, et al. Inhaled nitric oxide in premature neonates with severe hypoxaemic respiratory failure: A randomized controlled trial. Lancet. 1999;354(9184):1061-5. [pmid: 10509496].
11 Kinsella JP, Cutter GR, Walsh WF, et al. Early inhaled nitric oxide therapy in premature newborns with respiratory failure. N Engl J Med. 2006;355(4):354-64. [pmid: 16870914].
12 Watson RS, Clermont G, Kinsella JP, et al. Clinical and economic effects of iNO in premature newborns with respiratory failure at 1 year. Pediatrics. 2009;124(5):1333-43. [pmid: 19841128].
13 Schreiber MD, Gin-Mestan K, Marks JD, Huo D, Lee G, Srisuparp P. Inhaled Nitric Oxide in Premature Infants with the Respiratory Distress Syndrome. New Engl. J. Med. 2003;349(22):2099-107. [pmid: 14645637].
14 Mestan KK, Marks JD, Hecox K, Huo D, Schreiber MD. Neurodevelopmental outcomes of premature infants treated with inhaled nitric oxide. N Engl J Med. 2005;353(1):23-32. [pmid: 16000353].
15 Srisuparp P, Heitschmidt M, Schreiber MD. Inhaled nitric oxide therapy in premature infants with mild to moderate respiratory distress syndrome. J Med Assoc Thai. 2002;85(Suppl 2):S469-78. [pmid: 12403222].
16 Su PH, Chen JY. Inhaled nitric oxide in the management of preterm infants with severe respiratory failure. J Perinatol. 2008;28(2):112-6. [pmid: 17989696].
17 Subhedar NV, Ryan SW, Shaw NJ. Open randomised controlled trial of inhaled nitric oxide and early dexamethasone in high risk preterm infants. Arch Dis Child Fetal Neonatal Ed. 1997;77(3):F185-90. [pmid: 9462187].
18 Bennett AJ, Shaw NJ, Gregg JE, Subhedar NV. Neurodevelopmental outcome in high-risk preterm infants treated with inhaled nitric oxide. Acta Paediatr. 2001;90(5):573-6. [pmid: 11430720].
19 Van Meurs KP, Wright LL, Ehrenkranz RA, et al. Inhaled nitric oxide for premature infants with severe respiratory failure. N Engl J Med. 2005;353(1):13-22. [pmid: 16000352].
20 Chock VY, Van Meurs KP, Hintz SR, et al. Inhaled nitric oxide for preterm premature rupture of membranes, oligohydramnios, and pulmonary hypoplasia. Am J Perinatol. 2009;26(4):317-22. [pmid: 19067285].
21 Hintz SR, Van Meurs KP, Perritt R, et al. Neurodevelopmental outcomes of premature infants with severe respiratory failure enrolled in a randomized controlled trial of inhaled nitric oxide. J Pediatr. 2007;151(1):16-22. 22.e1. 3. [pmid: 17586184].
22 Van Meurs KP, Hintz SR, Ehrenkranz RA, et al. Inhaled nitric oxide in infants >1500 g and <34 weeks gestation with severe respiratory failure. J Perinatol. 2007;27(6):347-52. [pmid: 17443204].

### Reference List for Evidence Table 2

1 Banks BA, Seri I, Ischiropoulos H, Merrill J, Rychik J, Ballard RA. Changes in oxygenation with inhaled nitric oxide in severe bronchopul monary dysplasia. Pediatrics. 1999;103(3):610-8. [pmid: 10049965].
2 Cheung P-Y, Peliowski A, Robertson CMT. The outcome of very low birth weight neonates ((less-than or equal to) 1500 g) rescued by inhaled nitric oxide: Neurodevelopment in early childhood. J. Pediatr. 1998;133(6):735-9. [pmid: 9842035].
3 Clark PL, Ekekezie II, Kaftan HA, Castor CA, Truog WE. Safety and efficacy of nitric oxide in chronic lung disease. Arch Dis Child Fetal Neonatal Ed. 2002;86(1):F41-5. [pmid: 11815547].
4 Dewhurst C, Ibrahim H, Gothberg S, Jonsson B, Subhedar N. Use of inhaled nitric oxide in the new born period: Results from the European inhaled nitric oxide registry. Acta Paediatr. Int. J. Paediatr. 2010;99(6):854-60.
5 Kumar VH, Hutchison AA, Lakshminrusimha S, Morin FC 3rd, Wynn RJ, Ryan RM. Characteristics of pulmonary hypertension in preterm neonates. J Perinatol. 2007;27(4):214-9. [pmid: 17330053].
6 Uga N, Ishii T, Kawase Y, Arai H, Tada H. Nitric oxide inhalation therapy in very low-birthweight infants with hypoplastic lung due to oligohydramnios. Pediatr. Int. 2004;46(1):10-4. [pmid: 15043657].
7 Tanaka Y, Hayashi T, Kitajima H, Sumi K, Fujimura M. Inhaled nitric oxide therapy decreases the risk of cerebral palsy in preterm infants with persistent pulmonary hypertension of the newborn. Pediatrics. 2007;119(6):1159-64. [pmid: 17545384].
8 Yadav M, Emmerson AJ. Inhaled nitric oxide in premature neonates. Lancet. 1999;354(9196):2162-3. [pmid: 10609839].

### Reference List for Evidence Table 3

1 Ballard RA, Truog WE, Cnaan A, et al. Inhaled nitric oxide in preterm infants undergoing mechanical ventilation. New Engl. J. Med. 2006;355(4):343-53. [pmid: 16870913].
2 Hibbs AM, Walsh MC, Martin RJ, et al. One Year Respiratory Outcomes of the Preterm Infants Enrolled in the NO CLD Trial of Inhaled Nitric Oxide (iNO). N/A. 2007.
3 Walsh MC, Hibbs AM, Martin CR, et al. Two-year neurodevelopmental outcomes of ventilated preterm infants treated with inhaled nitric oxide. J Pediatr. 2010;156(4):556-61.e1. [pmid: 20138299].
4 Banks BA, Seri I, Ischiropoulos H, Merrill J, Rychik J, Ballard RA. Changes in oxygenation with inhaled nitric oxide in severe bronchopulmonary dysplasia. Pediatrics. 1999;103(3):610-8. [pmid: 10049965].
5 Cheung P-Y, Peliowski A, Robertson CMT. The outcome of very low birth weight neonates ((less-than or equal to)1500 g) rescued by inhaled nitric oxide: Neurodevelopment in early childhood. J. Pediatr. 1998;133(6):735-9. [pmid: 9842035].
6 Clark PL, Ekekezie II, Kaftan HA, Castor CA, Truog WE. Safety and efficacy of nitric oxide in chronic lung disease. Arch Dis Child Fetal Neonatal Ed. 2002;86(1):F41-5. [pmid: 11815547].
7 Dani C, Bertini G, Pezzati M, Filippi L, Cecchi A, Rubaltelli FF. Inhaled nitric oxide in very preterm infants with severe respiratory distress syndrome. Acta Paediatr. 2006;95(9):1116-23. [pmid: 16938760].
8 Dewhurst C, Ibrahim H, Gothberg S, Jonsson B, Subhedar N. Use of inhaled nitric oxide in the new born period: Results from the European inhaled nitric oxide registry. Acta Paediatr. Int. J. Paediatr. 2010;99(6):854-60.
9 Field D, Elbourne D, Truesdale A, et al. Neonatal Ventilation With Inhaled Nitric Oxide Versus Ventilatory Support Without Inhaled Nitric Oxide for Preterm Infants With Severe Respiratory Failure: the INNOVO multicentre randomised controlled trial (ISRCTN 17821339). Pediatrics. 2005;115(4):926-36. [pmid: 15805366].
10 Huddy CL, Bennett CC, Hardy P, et al. The INNOVO multicentre randomised controlled trial: neonatal ventilation with inhaled nitric oxide versus ventilatory support without nitric oxide for severe respiratory failure in preterm infants: follow up at 4-5 years. Arch Dis Child Fetal Neonatal Ed. 2008;93(6):F430-5. [pmid: 18375612].
11 Franco-Belgium Collaborative NO Trial Group. Early compared with delayed inhaled nitric oxide in moderately hypoxaemic neonates with respiratory failure: a randomised controlled trial. The Franco-Belgium Collaborative NO Trial Group. Lancet. 1999;354(9184):1066-71. [pmid: 10509497].
12 Hascoet JM, Fresson J, Claris O, et al. The safety and efficacy of nitric oxide therapy in premature infants. J. Pediatr. 2005;146(3):318-23. [pmid: 15756211].
13 Hamon I, Fresson J, Nicolas MB, Buchweiller MC, Franck P, Hascoet JM. Early inhaled nitric oxide improves oxidative balance in very preterm infants. Pediatr Res. 2005;57(5 Pt 1):637-43. [pmid: 15746261].
14 Kinsella JP, Walsh WF, Bose CL, et al. Inhaled nitric oxide in premature neonates with severe hypoxaemic respiratory failure: A randomised controlled trial. Lancet. 1999;354(9184):1061-5. [pmid: 10509496].
15 Kinsella JP, Cutter GR, Walsh WF, et al. Early inhaled nitric oxide therapy in premature newborns with respiratory failure. N Engl J Med. 2006;355(4):354-64. [pmid: 16870914].
16 Watson RS, Clermont G, Kinsella JP, et al. Clinical and economic effects of iNO in premature newborns with respiratory failure at 1 year. Pediatrics. 2009;124(5):1333-43. [pmid: 19841128].
17 Mercier JC, Hummler H, Durrmeyer X, et al. Inhaled nitric oxide for prevention of bronchopulmonary dysplasia in premature babies (EUNO): a randomised controlled trial. Lancet. 2010.
18 Schreiber MD, Gin-Mestan K, Marks JD, Huo D, Lee G, Srisuparp P. Inhaled Nitric Oxide in Premature Infants with the Respiratory Distress Syndrome. New Engl. J. Med. 2003;349(22):2099-107. [pmid: 14645637].
19 Mestan KK, Marks JD, Hecox K, Huo D, Schreiber MD. Neurodevelopmental outcomes of premature infants treated with inhaled nitric oxide. N Engl J Med. 2005;353(1):23-32. [pmid: 16000353].
20 Srisuparp P, Heitschmidt M, Schreiber MD. Inhaled nitric oxide therapy in premature infants with mild to moderate respiratory distress syndrome. J Med Assoc Thai. 2002;85(Suppl 2):S469-78. [pmid: 12403222].
21 Su PH, Chen JY. Inhaled nitric oxide in the management of preterm infants with severe respiratory failure. J Perinatol. 2008;28(2):112-6. [pmid: 17989696].
22 Subhedar NV, Ryan SW, Shaw NJ. Open randomised controlled trial of inhaled nitric oxide and early dexamethasone in high risk preterm infants. Arch Dis Child Fetal Neonatal Ed. 1997;77(3):F185-90. [pmid: 9462187].
23 Bennett AJ, Shaw NJ, Gregg JE, Subhedar NV. Neurodevelopmental outcome in high-risk preterm infants treated with inhaled nitric oxide. Acta Paediatr. 2001;90(5):573-6. [pmid: 11430720].
24 Tanaka Y, Hayashi T, Kitajima H, Sumi K, Fujimura M. Inhaled nitric oxide therapy decreases the risk of cerebral palsy in preterm infants with persistent pulmonary hypertension of the newborn. Pediatrics. 2007;119(6):1159-64. [pmid: 17545384].
25 Uga N, Ishii T, Kawase Y, Arai H, Tada H. Nitric oxide inhalation therapy in very low-birthweight infants with hypoplastic lung due to oligohydramnios. Pediatr. Int. 2004;46(1):10-4. [pmid: 15043657].
26 Van Meurs KP, Wright LL, Ehrenkranz RA, et al. Inhaled nitric oxide for premature infants with severe respiratory failure. N Engl J Med. 2005;353(1):13-22. [pmid: 16000352].
27 Chock VY, Van Meurs KP, Hintz SR, et al. Inhaled nitric oxide for preterm premature rupture of membranes, oligohydramnios, and pulmonary hypoplasia. Am J Perinatol. 2009;26(4):317-22. [pmid: 19067285].
28 Hintz SR, Van Meurs KP, Perritt R, et al. Neurodevelopmental outcomes of premature infants with severe respiratory failure enrolled in a randomized controlled trial of inhaled nitric oxide. J Pediatr. 2007;151(1):16-22. 22.e1. 3. [pmid: 17586184].
29 Van Meurs KP, Hintz SR, Ehrenkranz RA, et al. Inhaled nitric oxide in infants >1500 g and <34 weeks gestation with severe respiratory failure. J Perinatol. 2007;27(6):347-52. [pmid: 17443204].
30 Yadav M, Emmerson AJ. Inhaled nitric oxide in premature neonates. Lancet. 1999;354(9196):2162-3. [pmid: 10609839].

### Reference List for Evidence Table 4

1 Ballard RA, Truog WE, Cnaan A, et al. Inhaled nitric oxide in preterm infants undergoing mechanical ventilation. New Engl. J. Med. 2006;355(4):343-53. [pmid: 16870913].
2 Hibbs AM, Walsh MC, Martin RJ, et al. One Year Respiratory Outcomes of the Preterm Infants Enrolled in the NO CLD Trial of Inhaled Nitric Oxide (iNO). N/A. 2007.
3 Walsh MC, Hibbs AM, Martin CR, et al. Two-year neurodevelopmental outcomes of ventilated preterm infants treated with inhaled nitric oxide. J Pediatr. 2010;156(4):556-61.e1. [pmid: 20138299].
4 Banks BA, Seri I, Ischiropoulos H, Merrill J, Rychik J, Ballard RA. Changes in oxygenation with inhaled nitric oxide in severe bronchopulmonary dysplasia. Pediatrics. 1999;103(3):610-8. [pmid: 10049965].
5 Cheung P-Y, Peliowski A, Robertson CMT. The outcome of very low birth weight neonates ((less-than or equal to) 1500 g) rescued by inhaled nitric oxide: Neurodevelopment in early childhood. J. Pediatr. 1998;133(6):735-9. [pmid: 9842035].
6 Clark PL, Ekekezie II, Kaftan HA, Castor CA, Truog WE. Safety and efficacy of nitric oxide in chronic lung disease. Arch Dis Child Fetal Neonatal Ed. 2002;86(1):F41-5. [pmid: 11815547].
7 Dani C, Bertini G, Pezzati M, Filippi L, Cecchi A, Rubaltelli FF. Inhaled nitric oxide in very preterm infants with severe respiratory distress syndrome. Acta Paediatr. 2006;95(9):1116-23. [pmid: 16938760].
8 Dewhurst C, Ibrahim H, Gothberg S, Jonsson B, Subhedar N. Use of inhaled nitric oxide in the new born period: Results from the European inhaled nitric oxide registry. Acta Paediatr. Int. J. Paediatr. 2010;99(6):854-60.
9 Field D, Elbourne D, Truesdale A, et al. Neonatal Ventilation With Inhaled Nitric Oxide Versus Ventilatory Support Without Inhaled Nitric Oxide for Preterm Infants With Severe Respiratory Failure: the INNOVO multicentre randomised controlled trial (ISRCTN 17821339). Pediatrics. 2005;115(4):926-36. [pmid: 15805366].
10 Huddy CL, Bennett CC, Hardy P, et al. The INNOVO multicentre randomised controlled trial: neonatal ventilation with inhaled nitric oxide versus ventilatory support without nitric oxide for severe respiratory failure in preterm infants: follow up at 4-5 years. Arch Dis Child Fetal Neonatal Ed. 2008;93(6):F430-5. [pmid: 18375612].
11 Franco-Belgium Collaborative NO Trial Group. Early compared with delayed inhaled nitric oxide in moderately hypoxaemic neonates with respiratory failure: a randomised controlled trial. The Franco-Belgium Collaborative NO Trial Group. Lancet. 1999;354(9184):1066-71. [pmid: 10509497].
12 Hascoet JM, Fresson J, Claris O, et al. The safety and efficacy of nitric oxide therapy in premature infants. J. Pediatr. 2005;146(3):318-23. [pmid: 15756211].
13 Hamon I, Fresson J, Nicolas MB, Buchweiller MC, Franck P, Hascoet JM. Early inhaled nitric oxide improves oxidative balance in very preterm infants. Pediatr Res. 2005;57(5 Pt 1):637-43. [pmid: 15746261].
14 Kinsella JP, Walsh WF, Bose CL, et al. Inhaled nitric oxide in premature neonates with severe hypoxaemic respiratory failure: A randomised controlled trial. Lancet. 1999;354(9184):1061-5. [pmid: 10509496].
15 Kinsella JP, Cutter GR, Walsh WF, et al. Early inhaled nitric oxide therapy in premature newborns with respiratory failure. N Engl J Med. 2006;355(4):354-64. [pmid: 16870914].
16 Watson RS, Clermont G, Kinsella JP, et al. Clinical and economic effects of iNO in premature newborns with respiratory failure at 1 year. Pediatrics. 2009;124(5):1333-43. [pmid: 19841128].
17 Mercier JC, Hummler H, Durrmeyer X, et al. Inhaled nitric oxide for prevention of bronchopulmonary dysplasia in premature babies (EUNO): a randomised controlled trial. Lancet. 2010.
18 Schreiber MD, Gin-Mestan K, Marks JD, Huo D, Lee G, Srisuparp P. Inhaled Nitric Oxide in Premature Infants with the Respiratory Distress Syndrome. New Engl. J. Med. 2003;349(22):2099-107. [pmid: 14645637].
19 Mestan KK, Marks JD, Hecox K, Huo D, Schreiber MD. Neurodevelopmental outcomes of premature infants treated with inhaled nitric oxide. N Engl J Med. 2005;353(1):23-32. [pmid: 16000353].
20 Srisuparp P, Heitschmidt M, Schreiber MD. Inhaled nitric oxide therapy in premature infants with mild to moderate respiratory distress syndrome. J Med Assoc Thai. 2002;85(Suppl 2):S469-78. [pmid: 12403222].
21 Su PH, Chen JY. Inhaled nitric oxide in the management of preterm infants with severe respiratory failure. J Perinatol. 2008;28(2):112-6. [pmid: 17989696].
22 Subhedar NV, Ryan SW, Shaw NJ. Open randomised controlled trial of inhaled nitric oxide and early dexamethasone in high risk preterm infants. Arch Dis Child Fetal Neonatal Ed. 1997;77(3):F185-90. [pmid: 9462187].
23 Bennett AJ, Shaw NJ, Gregg JE, Subhedar NV. Neurodevelopmental outcome in high-risk preterm infants treated with inhaled nitric oxide. Acta Paediatr. 2001;90(5):573-6. [pmid: 11430720].
24 Tanaka Y, Hayashi T, Kitajima H, Sumi K, Fujimura M. Inhaled nitric oxide therapy decreases the risk of cerebral palsy in preterm infants with persistent pulmonary hypertension of the newborn. Pediatrics. 2007;119(6):1159-64. [pmid: 17545384].
25 Uga N, Ishii T, Kawase Y, Arai H, Tada H. Nitric oxide inhalation therapy in very low-birthweight infants with hypoplastic lung due to oligohydramnios. Pediatr. Int. 2004;46(1):10-4. [pmid: 15043657].
26 Van Meurs KP, Wright LL, Ehrenkranz RA, et al. Inhaled nitric oxide for premature infants with severe respiratory failure. N Engl J Med. 2005;353(1):13-22. [pmid: 16000352].
27 Chock VY, Van Meurs KP, Hintz SR, et al. Inhaled nitric oxide for preterm premature rupture of membranes, oligohydramnios, and pulmonary hypoplasia. Am J Perinatol. 2009;26(4):317-22. [pmid: 19067285].
28 Hintz SR, Van Meurs KP, Perritt R, et al. Neurodevelopmental outcomes of premature infants with severe respiratory failure enrolled in a randomized controlled trial of inhaled nitric oxide. J Pediatr. 2007;151(1):16-22. 22.e1. 3. [pmid: 17586184].
29 Van Meurs KP, Hintz SR, Ehrenkranz RA, et al. Inhaled nitric oxide in infants >1500 g and <34 weeks gestation with severe respiratory failure. J Perinatol. 2007;27(6):347-52. [pmid: 17443204].
30 Yadav M, Emmerson AJ. Inhaled nitric oxide in premature neonates. Lancet. 1999;354(9196):2162-3. [pmid: 10609839].

### Reference List for Evidence Table 5

1 Ballard RA, Truog WE, Cnaan A, et al. Inhaled nitric oxide in preterm infants undergoing mechanical ventilation. New Engl. J. Med. 2006;355(4):343-53. [pmid: 16870913].
2 Dani C, Bertini G, Pezzati M, Filippi L, Cecchi A, Rubaltelli FF. Inhaled nitric oxide in very preterm infants with severe respiratory distress syndrome. Acta Paediatr. 2006;95(9):1116-23. [pmid: 16938760].
3 Field D, Elbourne D, Truesdale A, et al. Neonatal Ventilation With Inhaled Nitric Oxide Versus Ventilatory Support Without Inhaled Nitric Oxide for Preterm Infants With Severe Respiratory Failure: the INNOVO multicentre randomised controlled trial (ISRCTN 17821339). Pediatrics. 2005;115(4):926-36. [pmid: 15805366].
4 Franco-Belgium Collaborative NO Trial Group. Early compared with delayed inhaled nitric oxide in moderately hypoxaemic neonates with respiratory failure: a randomised controlled trial. The Franco-Belgium Collaborative NO Trial Group. Lancet. 1999;354(9184):1066-71. [pmid: 10509497].
5 Hascoet JM, Fresson J, Claris O, et al. The safety and efficacy of nitric oxide therapy in premature infants. J. Pediatr. 2005;146(3):318-23. [pmid: 15756211].
6 Kinsella JP, Walsh WF, Bose CL, et al. Inhaled nitric oxide in premature neonates with severe hypoxaemic respiratory failure: A randomised controlled trial. Lancet. 1999;354(9184):1061-5. [pmid: 10509496].
7 Kinsella JP, Cutter GR, Walsh WF, et al. Early inhaled nitric oxide therapy in premature newborns with respiratory failure. N Engl J Med. 2006;355(4):354-64. [pmid: 16870914].
8 Mercier JC, Hummler H, Durrmeyer X, et al. Inhaled nitric oxide for prevention of bronchopulmonary dysplasia in premature babies (EUNO): a randomised controlled trial. Lancet. 2010.
9 Schreiber MD, Gin-Mestan K, Marks JD, Huo D, Lee G, Srisuparp P. Inhaled Nitric Oxide in Premature Infants with the Respiratory Distress Syndrome. New Engl. J. Med. 2003;349(22):2099-107. [pmid: 14645637].
10 Srisuparp P, Heitschmidt M, Schreiber MD. Inhaled nitric oxide therapy in premature infants with mild to moderate respiratory distress syndrome. J Med Assoc Thai. 2002;85(Suppl 2):S469-78. [pmid: 12403222].
11 Su PH, Chen JY. Inhaled nitric oxide in the management of preterm infants with severe respiratory failure. J Perinatol. 2008;28(2):112-6. [pmid: 17989696].
12 Subhedar NV, Ryan SW, Shaw NJ. Open randomised controlled trial of inhaled nitric oxide and early dexamethasone in high risk preterm infants. Arch Dis Child Fetal Neonatal Ed. 1997;77(3):F185-90. [pmid: 9462187].
13 Van Meurs KP, Wright LL, Ehrenkranz RA, et al. Inhaled nitric oxide for premature infants with severe respiratory failure. N Engl J Med. 2005;353(1):13-22. [pmid: 16000352].
14 Van Meurs KP, Hintz SR, Ehrenkranz RA, et al. Inhaled nitric oxide in infants >1500 g and <34 weeks gestation with severe respiratory failure. J Perinatol. 2007;27(6):347-52. [pmid: 17443204].

### Reference List for Evidence Table 6

1 Ballard RA, Truog WE, Cnaan A, et al. Inhaled nitric oxide in preterm infants undergoing mechanical ventilation. New Engl. J. Med. 2006;355(4):343-53. [pmid: 16870913].
2 Dani C, Bertini G, Pezzati M, Filippi L, Cecchi A, Rubaltelli FF. Inhaled nitric oxide in very preterm infants with severe respiratory distress syndrome. Acta Paediatr. 2006;95(9):1116-23. [pmid: 16938760].
3 Field D, Elbourne D, Truesdale A, et al. Neonatal Ventilation With Inhaled Nitric Oxide Versus Ventilatory Support Without Inhaled Nitric Oxide for Preterm Infants With Severe Respiratory Failure: the INNOVO multicentre randomised controlled trial (ISRCTN 17821339). Pediatrics. 2005;115(4):926-36. [pmid: 15805366].
4 Franco-Belgium Collaborative NO Trial Group. Early compared with delayed inhaled nitric oxide in moderately hypoxaemic neonates with respiratory failure: a randomised controlled trial. The Franco-Belgium Collaborative NO Trial Group. Lancet. 1999;354(9184):1066-71. [pmid: 10509497].
5 Kinsella JP, Cutter GR, Walsh WF, et al. Early inhaled nitric oxide therapy in premature newborns with respiratory failure. N Engl J Med. 2006;355(4):354-64. [pmid: 16870914].
6 Kinsella JP, Walsh WF, Bose CL, et al. Inhaled nitric oxide in premature neonates with severe hypoxaemic respiratory failure: A randomised controlled trial. Lancet. 1999;354(9184):1061-5. [pmid: 10509496].
7 Mercier JC, Hummler H, Durrmeyer X, et al. Inhaled nitric oxide for prevention of bronchopulmonary dysplasia in premature babies (EUNO): a randomised controlled trial. Lancet. 2010.
8 Schreiber MD, Gin-Mestan K, Marks JD, Huo D, Lee G, Srisuparp P. Inhaled Nitric Oxide in Premature Infants with the Respiratory Distress Syndrome. New Engl. J. Med. 2003;349(22):2099-107. [pmid: 14645637].
9 Su PH, Chen JY. Inhaled nitric oxide in the management of preterm infants with severe respiratory failure. J Perinatol. 2008;28(2):112-6. [pmid: 17989696].
10 Subhedar NV, Ryan SW, Shaw NJ. Open randomised controlled trial of inhaled nitric oxide and early dexamethasone in high risk preterm infants. Arch Dis Child Fetal Neonatal Ed. 1997;77(3):F185-90. [pmid: 9462187].
11 Van Meurs KP, Hintz SR, Ehrenkranz RA, et al. Inhaled nitric oxide in infants >1500 g and <34 weeks gestation with severe respiratory failure. J Perinatol. 2007;27(6):347-52. [pmid: 17443204].
12 Van Meurs KP, Wright LL, Ehrenkranz RA, et al. Inhaled nitric oxide for premature infants with severe respiratory failure. N Engl J Med. 2005;353(1):13-22. [pmid: 16000352].
13 Hascoet JM, Fresson J, Claris O, et al. The safety and efficacy of nitric oxide therapy in premature infants. J. Pediatr. 2005;146(3):318-23. [pmid: 15756211].

### Reference List for Evidence Table 7

1 Ballard RA, Truog WE, Cnaan A, et al. Inhaled nitric oxide in preterm infants undergoing mechanical ventilation. New Engl. J. Med. 2006;355(4):343-53. [pmid: 16870913].
2 Dani C, Bertini G, Pezzati M, Filippi L, Cecchi A, Rubaltelli FF. Inhaled nitric oxide in very preterm infants with severe respiratory distress syndrome. Acta Paediatr. 2006;95(9):1116-23. [pmid: 16938760].
3 Field D, Elbourne D, Truesdale A, et al. Neonatal Ventilation With Inhaled Nitric Oxide Versus Ventilatory Support Without Inhaled Nitric Oxide for Preterm Infants With Severe Respiratory Failure: the INNOVO multicentre randomised controlled trial (ISRCTN 17821339). Pediatrics. 2005;115(4):926-36. [pmid: 15805366].
4 Franco-Belgium Collaborative NO Trial Group. Early compared with delayed inhaled nitric oxide in moderately hypoxaemic neonates with respiratory failure: a randomised controlled trial. The Franco-Belgium Collaborative NO Trial Group. Lancet. 1999;354(9184):1066-71. [pmid: 10509497].
5 Kinsella JP, Walsh WF, Bose CL, et al. Inhaled nitric oxide in premature neonates with severe hypoxaemic respiratory failure: A randomised controlled trial. Lancet. 1999;354(9184):1061-5. [pmid: 10509496].
6 Kinsella JP, Cutter GR, Walsh WF, et al. Early inhaled nitric oxide therapy in premature newborns with respiratory failure. N Engl J Med. 2006;355(4):354-64. [pmid: 16870914].
7 Mercier JC, Hummler H, Durrmeyer X, et al. Inhaled nitric oxide for prevention of bronchopulmonary dysplasia in premature babies (EUNO): a randomised controlled trial. Lancet. 2010.
8 Schreiber MD, Gin-Mestan K, Marks JD, Huo D, Lee G, Srisuparp P. Inhaled Nitric Oxide in Premature Infants with the Respiratory Distress Syndrome. New Engl. J. Med. 2003;349(22):2099-107. [pmid: 14645637].
9 Su PH, Chen JY. Inhaled nitric oxide in the management of preterm infants with severe respiratory failure. J Perinatol. 2008;28(2):112-6. [pmid: 17989696].
10 Subhedar NV, Ryan SW, Shaw NJ. Open randomised controlled trial of inhaled nitric oxide and early dexamethasone in high risk preterm infants. Arch Dis Child Fetal Neonatal Ed. 1997;77(3):F185-90. [pmid: 9462187].
11 Van Meurs KP, Hintz SR, Ehrenkranz RA, et al. Inhaled nitric oxide in infants >1500 g and <34 weeks gestation with severe respiratory failure. J Perinatol. 2007;27(6):347-52. [pmid: 17443204].
12 Van Meurs KP, Wright LL, Ehrenkranz RA, et al. Inhaled nitric oxide for premature infants with severe respiratory failure. N Engl J Med. 2005;353(1):13-22. [pmid: 16000352].

### Reference List for Evidence Table 8

1 Dani C, Bertini G, Pezzati M, Filippi L, Cecchi A, Rubaltelli FF. Inhaled nitric oxide in very preterm infants with severe respiratory distress syndrome. Acta Paediatr. 2006;95(9):1116-23. [pmid: 16938760].
2 Hascoet JM, Fresson J, Claris O, et al. The safety and efficacy of nitric oxide therapy in premature infants. J. Pediatr. 2005;146(3):318-23. [pmid: 15756211].
3 Kinsella JP, Walsh WF, Bose CL, et al. Inhaled nitric oxide in premature neonates with severe hypoxaemic respiratory failure: A randomised controlled trial. Lancet. 1999;354(9184):1061-5. [pmid: 10509496].
4 Su PH, Chen JY. Inhaled nitric oxide in the management of preterm infants with severe respiratory failure. J Perinatol. 2008;28(2):112-6. [pmid: 17989696].
5 Kinsella JP, Cutter GR, Walsh WF, et al. Early inhaled nitric oxide therapy in premature newborns with respiratory failure. N Engl J Med. 2006;355(4):354-64. [pmid: 16870914].
6 Mercier JC, Hummler H, Durrmeyer X, et al. Inhaled nitric oxide for prevention of bronchopulmonary dysplasia in premature babies (EUNO): a randomised controlled trial. Lancet. 2010.
7 Srisuparp P, Heitschmidt M, Schreiber MD. Inhaled nitric oxide therapy in premature infants with mild to moderate respiratory distress syndrome. J Med Assoc Thai. 2002;85(Suppl 2):S469-78. [pmid: 12403222].
8 Ballard RA, Truog WE, Cnaan A, et al. Inhaled nitric oxide in preterm infants undergoing mechanical ventilation. New Engl. J. Med. 2006;355(4):343-53. [pmid: 16870913].
9 Franco-Belgium Collaborative NO Trial Group. Early compared with delayed inhaled nitric oxide in moderately hypoxaemic neonates with respiratory failure: a randomised controlled trial. The Franco-Belgium Collaborative NO Trial Group. Lancet. 1999;354(9184):1066-71. [pmid: 10509497].
10 Schreiber MD, Gin-Mestan K, Marks JD, Huo D, Lee G, Srisuparp P. Inhaled Nitric Oxide in Premature Infants with the Respiratory Distress Syndrome. New Engl. J. Med. 2003;349(22):2099-107. [pmid: 14645637].
11 Van Meurs KP, Hintz SR, Ehrenkranz RA, et al. Inhaled nitric oxide in infants >1500 g and <34 weeks gestation with severe respiratory failure. J Perinatol. 2007;27(6):347-52. [pmid: 17443204].
12 Van Meurs KP, Wright LL, Ehrenkranz RA, et al. Inhaled nitric oxide for premature infants with severe respiratory failure. N Engl J Med. 2005;353(1):13-22. [pmid: 16000352].

### Reference List for Evidence Table 9

1 Ballard RA, Truog WE, Cnaan A, et al. Inhaled nitric oxide in preterm infants undergoing mechanical ventilation. New Engl. J. Med. 2006;355(4):343-53. [pmid: 16870913].
2 Field D, Elbourne D, Truesdale A, et al. Neonatal Ventilation With Inhaled Nitric Oxide Versus Ventilatory Support Without Inhaled Nitric Oxide for Preterm Infants With Severe Respiratory Failure: the INNOVO multicentre randomised controlled trial (ISRCTN 17821339). Pediatrics. 2005;115(4):926-36. [pmid: 15805366].
3 Schreiber MD, Gin-Mestan K, Marks JD, Huo D, Lee G, Srisuparp P. Inhaled Nitric Oxide in Premature Infants with the Respiratory Distress Syndrome. New Engl. J. Med. 2003;349(22):2099-107. [pmid: 14645637].
4 Kinsella JP, Cutter GR, Walsh WF, et al. Early inhaled nitric oxide therapy in premature newborns with respiratory failure. N Engl J Med. 2006;355(4):354-64. [pmid: 16870914].
5 Srisuparp P, Heitschmidt M, Schreiber MD. Inhaled nitric oxide therapy in premature infants with mild to moderate respiratory distress syndrome. J Med Assoc Thai. 2002;85(Suppl 2):S469-78. [pmid: 12403222].
6 Su PH, Chen JY. Inhaled nitric oxide in the management of preterm infants with severe respiratory failure. J Perinatol. 2008;28(2):112-6. [pmid: 17989696].
7 Subhedar NV, Ryan SW, Shaw NJ. Open randomised controlled trial of inhaled nitric oxide and early dexamethasone in high risk preterm infants. Arch Dis Child Fetal Neonatal Ed. 1997;77(3):F185-90. [pmid: 9462187].
8 Mercier JC, Hummler H, Durrmeyer X, et al. Inhaled nitric oxide for prevention of bronchopulmonary dysplasia in premature babies (EUNO): a randomised controlled trial. Lancet. 2010.
9 Dani C, Bertini G, Pezzati M, Filippi L, Cecchi A, Rubaltelli FF. Inhaled nitric oxide in very preterm infants with severe respiratory distress syndrome. Acta Paediatr. 2006;95(9):1116-23. [pmid: 16938760].
10 Kinsella JP, Walsh WF, Bose CL, et al. Inhaled nitric oxide in premature neonates with severe hypoxaemic respiratory failure: A randomised controlled trial. Lancet. 1999;354(9184):1061-5. [pmid: 10509496].
11 Hascoet JM, Fresson J, Claris O, et al. The safety and efficacy of nitric oxide therapy in premature infants. J. Pediatr. 2005;146(3):318-23. [pmid: 15756211].
12 Van Meurs KP, Hintz SR, Ehrenkranz RA, et al. Inhaled nitric oxide in infants >1500 g and <34 weeks gestation with severe respiratory failure. J Perinatol. 2007;27(6):347-52. [pmid: 17443204].
13 Van Meurs KP, Wright LL, Ehrenkranz RA, et al. Inhaled nitric oxide for premature infants with severe respiratory failure. N Engl J Med. 2005;353(1):13-22. [pmid: 16000352].

### Reference List for Evidence Table 10

1 Bennett AJ, Shaw NJ, Gregg JE, Subhedar NV. Neurodevelopmental outcome in high-risk preterm infants treated with inhaled nitric oxide. Acta Paediatr. 2001;90(5):573-6. [pmid: 11430720].
2 Hintz SR, Van Meurs KP, Perritt R, et al. Neurodevelopmental outcomes of premature infants with severe respiratory failure enrolled in a randomized controlled trial of inhaled nitric oxide. J Pediatr. 2007;151(1):16-22. 22.e1. 3. [pmid: 17586184].
3 Huddy CL, Bennett CC, Hardy P, et al. The INNOVO multicentre randomised controlled trial: neonatal ventilation with inhaled nitric oxide versus ventilatory support without nitric oxide for severe respiratory failure in preterm infants: follow up at 4-5 years. Arch Dis Child Fetal Neonatal Ed. 2008;93(6):F430-5. [pmid: 18375612].
4 Walsh MC, Hibbs AM, Martin CR, et al. Two-year neurodevelopmental outcomes of ventilated preterm infants treated with inhaled nitric oxide. J Pediatr. 2010;156(4):556-61.e1. [pmid: 20138299].
5 Watson RS, Clermont G, Kinsella JP, et al. Clinical and economic effects of iNO in premature newborns with respiratory failure at 1 year. Pediatrics. 2009;124(5):1333-43. [pmid: 19841128].
6 Mestan KK, Marks JD, Hecox K, Huo D, Schreiber MD. Neurodevelopmental outcomes of premature infants treated with inhaled nitric oxide. N Engl J Med. 2005;353(1):23-32. [pmid: 16000353].

### Reference List for Evidence Table 11

1 Bennett AJ, Shaw NJ, Gregg JE, Subhedar NV. Neurodevelopmental outcome in high-risk preterm infants treated with inhaled nitric oxide. Acta Paediatr. 2001;90(5):573-6. [pmid: 11430720].
2 Hintz SR, Van Meurs KP, Perritt R, et al. Neurodevelopmental outcomes of premature infants with severe respiratory failure enrolled in a randomized controlled trial of inhaled nitric oxide. J Pediatr. 2007;151(1):16-22. 22.e1. 3. [pmid: 17586184].
3 Huddy CL, Bennett CC, Hardy P, et al. The INNOVO multicentre randomised controlled trial: neonatal ventilation with inhaled nitric oxide versus ventilatory support without nitric oxide for severe respiratory failure in preterm infants: follow up at 4-5 years. Arch Dis Child Fetal Neonatal Ed. 2008;93(6):F430-5. [pmid: 18375612].
4 Mestan KK, Marks JD, Hecox K, Huo D, Schreiber MD. Neurodevelopmental outcomes of premature infants treated with inhaled nitric oxide. N Engl J Med. 2005;353(1):23-32. [pmid: 16000353].
5 Tanaka Y, Hayashi T, Kitajima H, Sumi K, Fujimura M. Inhaled nitric oxide therapy decreases the risk of cerebral palsy in preterm infants with persistent pulmonary hypertension of the newborn. Pediatrics. 2007;119(6):1159-64. [pmid: 17545384].
6 Van Meurs KP, Hintz SR, Ehrenkranz RA, et al. Inhaled nitric oxide in infants >1500 g and <34 weeks gestation with severe respiratory failure. J Perinatol. 2007;27(6):347-52. [pmid: 17443204].
7 Walsh MC, Hibbs AM, Martin CR, et al. Two-year neurodevelopmental outcomes of ventilated preterm infants treated with inhaled nitric oxide. J Pediatr. 2010;156(4):556-61.e1. [pmid: 20138299].

### Reference List for Evidence Table 12

1 Hintz SR, Van Meurs KP, Perritt R, et al. Neurodevelopmental outcomes of premature infants with severe respiratory failure enrolled in a randomized controlled trial of inhaled nitric oxide. J Pediatr. 2007;151(1):16-22. 22.e1. 3. [pmid: 17586184].
2 Huddy CL, Bennett CC, Hardy P, et al. The INNOVO multicentre randomised controlled trial: neonatal ventilation with inhaled nitric oxide versus ventilatory support without nitric oxide for severe respiratory failure in preterm infants: follow up at 4-5 years. Arch Dis Child Fetal Neonatal Ed. 2008;93(6):F430-5. [pmid: 18375612].
3 Mestan KK, Marks JD, Hecox K, Huo D, Schreiber MD. Neurodevelopmental outcomes of premature infants treated with inhaled nitric oxide. N Engl J Med. 2005;353(1):23-32. [pmid: 16000353].
4 Van Meurs KP, Hintz SR, Ehrenkranz RA, et al. Inhaled nitric oxide in infants >1500 g and <34 weeks gestation with severe respiratory failure. J Perinatol. 2007;27(6):347-52. [pmid: 17443204].
5 Walsh MC, Hibbs AM, Martin CR, et al. Two-year neurodevelopmental outcomes of ventilated preterm infants treated with inhaled nitric oxide. J Pediatr. 2010;156(4):556-61.e1. [pmid: 20138299].

### Reference List for Evidence Table 13

1 Bennett AJ, Shaw NJ, Gregg JE, Subhedar NV. Neurodevelopmental outcome in high-risk preterm infants treated with inhaled nitric oxide. Acta Paediatr. 2001;90(5):573-6. [pmid: 11430720].
2 Field D, Elbourne D, Truesdale A, et al. Neonatal Ventilation With Inhaled Nitric Oxide Versus Ventilatory Support Without Inhaled Nitric Oxide for Preterm Infants With Severe Respiratory Failure: the INNOVO multicentre randomised controlled trial (ISRCTN 17821339). Pediatrics. 2005;115(4):926-36. [pmid: 15805366].
3 Huddy CL, Bennett CC, Hardy P, et al. The INNOVO multicentre randomised controlled trial: neonatal ventilation with inhaled nitric oxide versus ventilatory support without nitric oxide for severe respiratory failure in preterm infants: follow up at 4-5 years. Arch Dis Child Fetal Neonatal Ed. 2008;93(6):F430-5. [pmid: 18375612].
4 Mestan KK, Marks JD, Hecox K, Huo D, Schreiber MD. Neurodevelopmental outcomes of premature infants treated with inhaled nitric oxide. N Engl J Med. 2005;353(1):23-32. [pmid: 16000353].
5 Van Meurs KP, Hintz SR, Ehrenkranz RA, et al. Inhaled nitric oxide in infants >1500 g and <34 weeks gestation with severe respiratory failure. J Perinatol. 2007;27(6):347-52. [pmid: 17443204].
6 Walsh MC, Hibbs AM, Martin CR, et al. Two-year neurodevelopmental outcomes of ventilated preterm infants treated with inhaled nitric oxide. J Pediatr. 2010;156(4):556-61.e1. [pmid: 20138299].
7 Watson RS, Clermont G, Kinsella JP, et al. Clinical and economic effects of iNO in premature newborns with respiratory failure at 1 year. Pediatrics. 2009;124(5):1333-43. [pmid: 19841128].

### Reference List for Evidence Table 14

1 Bennett AJ, Shaw NJ, Gregg JE, Subhedar NV. Neurodevelopmental outcome in high-risk preterm infants treated with inhaled nitric oxide. Acta Paediatr. 2001;90(5):573-6. [pmid: 11430720].
2 Hintz SR, Van Meurs KP, Perritt R, et al. Neurodevelopmental outcomes of premature infants with severe respiratory failure enrolled in a randomized controlled trial of inhaled nitric oxide. J Pediatr. 2007;151(1):16-22. 22.e1. 3. [pmid: 17586184].
3 Huddy CL, Bennett CC, Hardy P, et al. The INNOVO multicentre randomised controlled trial: neonatal ventilation with inhaled nitric oxide versus ventilatory support without nitric oxide for severe respiratory failure in preterm infants: follow up at 4-5 years. Arch Dis Child Fetal Neonatal Ed. 2008;93(6):F430-5. [pmid: 18375612].
4 Mestan KK, Marks JD, Hecox K, Huo D, Schreiber MD. Neurodevelopmental outcomes of premature infants treated with inhaled nitric oxide. N Engl J Med. 2005;353(1):23-32. [pmid: 16000353].
5 Van Meurs KP, Hintz SR, Ehrenkranz RA, et al. Inhaled nitric oxide in infants >1500 g and <34 weeks gestation with severe respiratory failure. J Perinatol. 2007;27(6):347-52. [pmid: 17443204].
6 Walsh MC, Hibbs AM, Martin CR, et al. Two-year neurodevelopmental outcomes of ventilated preterm infants treated with inhaled nitric oxide. J Pediatr. 2010;156(4):556-61.e1. [pmid: 20138299].
7 Watson RS, Clermont G, Kinsella JP, et al. Clinical and economic effects of iNO in premature newborns with respiratory failure at 1 year. Pediatrics. 2009;124(5):1333-43. [pmid: 19841128].

### Reference List for Evidence Table 15

1 Field D, Elbourne D, Truesdale A, et al. Neonatal Ventilation With Inhaled Nitric Oxide Versus Ventilatory Support Without Inhaled Nitric Oxide for Preterm Infants With Severe Respiratory Failure: the INNOVO multicentre randomised controlled trial (ISRCTN 17821339). Pediatrics. 2005;115(4):926-36. [pmid: 15805366].
2 Huddy CL, Bennett CC, Hardy P, et al. The INNOVO multicentre randomised controlled trial: neonatal ventilation with inhaled nitric oxide versus ventilatory support without nitric oxide for severe respiratory failure in preterm infants: follow up at 4-5 years. Arch Dis Child Fetal Neonatal Ed. 2008;93(6):F430-5. [pmid: 18375612].
3 Hibbs AM, Walsh MC, Martin RJ, et al. One Year Respiratory Outcomes of the Preterm Infants Enrolled in the NO CLD Trial of Inhaled Nitric Oxide (iNO). N/A. 2007.
4 Cheung P-Y, Peliowski A, Robertson CMT. The outcome of very low birth weight neonates ((less-than or equal to)1500 g) rescued by inhaled nitric oxide: Neurodevelopment in early childhood. J. Pediatr. 1998;133(6):735-9. [pmid: 9842035].
5 Clark PL, Ekekezie II, Kaftan HA, Castor CA, Truog WE. Safety and efficacy of nitric oxide in chronic lung disease. Arch Dis Child Fetal Neonatal Ed. 2002;86(1):F41-5. [pmid: 11815547].
6 Watson RS, Clermont G, Kinsella JP, et al. Clinical and economic effects of iNO in premature newborns with respiratory failure at 1 year. Pediatrics. 2009;124(5):1333-43. [pmid: 19841128].
7 Mestan KK, Marks JD, Hecox K, Huo D, Schreiber MD. Neurodevelopmental outcomes of premature infants treated with inhaled nitric oxide. N Engl J Med. 2005;353(1):23-32. [pmid: 16000353].
8 Walsh MC, Hibbs AM, Martin CR, et al. Two-year neurodevelopmental outcomes of ventilated preterm infants treated with inhaled nitric oxide. J Pediatr. 2010;156(4):556-61.e1. [pmid: 20138299].
9 Hintz SR, Van Meurs KP, Perritt R, et al. Neurodevelopmental outcomes of premature infants with severe respiratory failure enrolled in a randomized controlled trial of inhaled nitric oxide. J Pediatr. 2007;151(1):16-22. 22.e1. 3. [pmid: 17586184].

### Reference List for Evidence Table 16

1 Chock VY, Van Meurs KP, Hintz SR, et al. Inhaled nitric oxide for preterm premature rupture of membranes, oligohydramnios, and pulmonary hypoplasia. Am J Perinatol. 2009;26(4):317-22. [pmid: 19067285].
2 Field D, Elbourne D, Truesdale A, et al. Neonatal Ventilation With Inhaled Nitric Oxide Versus Ventilatory Support Without Inhaled Nitric Oxide for Preterm Infants With Severe Respiratory Failure: the INNOVO multicentre randomised controlled trial (ISRCTN 17821339). Pediatrics. 2005;115(4):926-36. [pmid: 15805366].
3 Kinsella JP, Cutter GR, Walsh WF, et al. Early inhaled nitric oxide therapy in premature newborns with respiratory failure. N Engl J Med. 2006;355(4):354-64. [pmid: 16870914].
4 Schreiber MD, Gin-Mestan K, Marks JD, Huo D, Lee G, Srisuparp P. Inhaled Nitric Oxide in Premature Infants with the Respiratory Distress Syndrome. New Engl. J. Med. 2003;349(22):2099-107. [pmid: 14645637].
5 Van Meurs KP, Wright LL, Ehrenkranz RA, et al. Inhaled nitric oxide for premature infants with severe respiratory failure. N Engl J Med. 2005;353(1):13-22. [pmid: 16000352].
6 Ballard RA, Truog WE, Cnaan A, et al. Inhaled nitric oxide in preterm infants undergoing mechanical ventilation. New Engl. J. Med. 2006;355(4):343-53. [pmid: 16870913].
7 Banks BA, Seri I, Ischiropoulos H, Merrill J, Rychik J, Ballard RA. Changes in oxygenation with inhaled nitric oxide in severe bronchopulmonary dysplasia. Pediatrics. 1999;103(3):610-8. [pmid: 10049965].
8 Hintz SR, Van Meurs KP, Perritt R, et al. Neurodevelopmental outcomes of premature infants with severe respiratory failure enrolled in a randomized controlled trial of inhaled nitric oxide. J Pediatr. 2007;151(1):16-22. 22.e1. 3. [pmid: 17586184].
9 Kumar VH, Hutchison AA, Lakshminrusimha S, Morin FC 3rd, Wynn RJ, Ryan RM. Characteristics of pulmonary hypertension in preterm neonates. J Perinatol. 2007;27(4):214-9. [pmid: 17330053].
10 Yadav M, Emmerson AJ. Inhaled nitric oxide in premature neonates. Lancet. 1999;354(9196):2162-3. [pmid: 10609839].
11 Van Meurs KP, Hintz SR, Ehrenkranz RA, et al. Inhaled nitric oxide in infants >1500 g and <34 weeks gestation with severe respiratory failure. J Perinatol. 2007;27(6):347-52. [pmid: 17443204].
12 Watson RS, Clermont G, Kinsella JP, et al. Clinical and economic effects of iNO in premature newborns with respiratory failure at 1 year. Pediatrics. 2009;124(5):1333-43. [pmid: 19841128].
13 Uga N, Ishii T, Kawase Y, Arai H, Tada H. Nitric oxide inhalation therapy in very low-birthweight infants with hypoplastic lung due to oligohydramnios. Pediatr. Int. 2004;46(1):10-4. [pmid: 15043657].

### Reference List for Evidence Table 17

1 Ballard RA, Truog WE, Cnaan A, et al. Inhaled nitric oxide in preterm infants undergoing mechanical ventilation. New Engl. J. Med. 2006;355(4):343-53. [pmid: 16870913].
2 Dani C, Bertini G, Pezzati M, Filippi L, Cecchi A, Rubaltelli FF. Inhaled nitric oxide in very preterm infants with severe respiratory distress syndrome. Acta Paediatr. 2006;95(9):1116-23. [pmid: 16938760].
3 Field D, Elbourne D, Truesdale A, et al. Neonatal Ventilation With Inhaled Nitric Oxide Versus Ventilatory Support Without Inhaled Nitric Oxide for Preterm Infants With Severe Respiratory Failure: the INNOVO multicentre randomised controlled trial (ISRCTN 17821339). Pediatrics. 2005;115(4):926-36. [pmid: 15805366].
4 Franco-Belgium Collaborative NO Trial Group. Early compared with delayed inhaled nitric oxide in moderately hypoxaemic neonates with respiratory failure: a randomised controlled trial. The Franco-Belgium Collaborative NO Trial Group. Lancet. 1999;354(9184):1066-71. [pmid: 10509497].
5 Kinsella JP, Walsh WF, Bose CL, et al. Inhaled nitric oxide in premature neonates with severe hypoxaemic respiratory failure: A randomised controlled trial. Lancet. 1999;354(9184):1061-5. [pmid: 10509496].
6 Kinsella JP, Cutter GR, Walsh WF, et al. Early inhaled nitric oxide therapy in premature newborns with respiratory failure. N Engl J Med. 2006;355(4):354-64. [pmid: 16870914].
7 Mercier JC, Hummler H, Durrmeyer X, et al. Inhaled nitric oxide for prevention of bronchopulmonary dysplasia in premature babies (EUNO): a randomised controlled trial. Lancet. 2010.
8 Schreiber MD, Gin-Mestan K, Marks JD, Huo D, Lee G, Srisuparp P. Inhaled Nitric Oxide in Premature Infants with the Respiratory Distress Syndrome. New Engl. J. Med. 2003;349(22):2099-107. [pmid: 14645637].
9 Su PH, Chen JY. Inhaled nitric oxide in the management of preterm infants with severe respiratory failure. J Perinatol. 2008;28(2):112-6. [pmid: 17989696].
10 Subhedar NV, Ryan SW, Shaw NJ. Open randomised controlled trial of inhaled nitric oxide and early dexamethasone in high risk preterm infants. Arch Dis Child Fetal Neonatal Ed. 1997;77(3):F185-90. [pmid: 9462187].
11 Van Meurs KP, Hintz SR, Ehrenkranz RA, et al. Inhaled nitric oxide in infants >1500 g and <34 weeks gestation with severe respiratory failure. J Perinatol. 2007;27(6):347-52. [pmid: 17443204].
12 Van Meurs KP, Wright LL, Ehrenkranz RA, et al. Inhaled nitric oxide for premature infants with severe respiratory failure. N Engl J Med. 2005;353(1):13-22. [pmid: 16000352].
13 Hamon I, Fresson J, Nicolas MB, Buchweiller MC, Franck P, Hascoet JM. Early inhaled nitric oxide improves oxidative balance in very preterm infants. Pediatr Res. 2005;57(5 Pt 1):637-43. [pmid: 15746261].
14 Banks BA, Seri I, Ischiropoulos H, Merrill J, Rychik J, Ballard RA. Changes in oxygenation with inhaled nitric oxide in severe bronchopulmonary dysplasia. Pediatrics. 1999;103(3):610-8. [pmid: 10049965].
15 Bennett AJ, Shaw NJ, Gregg JE, Subhedar NV. Neurodevelopmental outcome in high-risk preterm infants treated with inhaled nitric oxide. Acta Paediatr. 2001;90(5):573-6. [pmid: 11430720].
16 Hascoet JM, Fresson J, Claris O, et al. The safety and efficacy of nitric oxide therapy in premature infants. J. Pediatr. 2005;146(3):318-23. [pmid: 15756211].
17 Hintz SR, Van Meurs KP, Perritt R, et al. Neurodevelopmental outcomes of premature infants with severe respiratory failure enrolled in a randomized controlled trial of inhaled nitric oxide. J Pediatr. 2007;151(1):16-22. 22.e1. 3. [pmid: 17586184].
18 Huddy CL, Bennett CC, Hardy P, et al. The INNOVO multicentre randomised controlled trial: neonatal ventilation with inhaled nitric oxide versus ventilatory support without nitric oxide for severe respiratory failure in preterm infants: follow up at 4-5 years. Arch Dis Child Fetal Neonatal Ed. 2008;93(6):F430-5. [pmid: 18375612].
19 Srisuparp P, Heitschmidt M, Schreiber MD. Inhaled nitric oxide therapy in premature infants with mild to moderate respiratory distress syndrome. J Med Assoc Thai. 2002;85(Suppl 2):S469-78. [pmid: 12403222].
20 Walsh MC, Hibbs AM, Martin CR, et al. Two-year neurodevelopmental outcomes of ventilated preterm infants treated with inhaled nitric oxide. J Pediatr. 2010;156(4):556-61.e1. [pmid: 20138299].
21 Watson RS, Clermont G, Kinsella JP, et al. Clinical and economic effects of iNO in premature newborns with respiratory failure at 1 year. Pediatrics. 2009;124(5):1333-43. [pmid: 19841128].
22 Mestan KK, Marks JD, Hecox K, Huo D, Schreiber MD. Neurodevelopmental outcomes of premature infants treated with inhaled nitric oxide. N Engl J Med. 2005;353(1):23-32. [pmid: 16000353].