# List of Excluded Articles

Caution over nitric oxide. Pharm. J. 2003;271(7279):818. No original data.
Nitric oxide to prevent bronchopulmonary dysplasia. Arch. Dis. Child. 2006;91(12):1022. No original data.
Abman S. H., Kinsella J. P. Inhaled nitric oxide for persistent pulmonary hypertension of the newborn: the physiology matters!. Pediatrics 95. 96(6):1153-5. No original data.
Abman S. H., Kinsella J. P. Inhaled nitric oxide therapy of pulmonary hypertension and respiratory failure in premature and term neonates. Adv. Pharmacol. 95. 34:457-474. No original data.
Abman S. H. Inhaled nitric oxide therapy of severe neonatal pulmonary hypertension. ACTA Anaesthesiol. Scand. Suppl. 95. 39(105):65-68. No original data.
Abman S. H. Neonatal pulmonary hypertension: A physiologic approach to treatment. Pediatr. Pulmonol. 2004;37(Suppl. 26):127-128. No original data.
Abman S. H. New developments in the pathogenesis and treatment of neonatal pulmonary hypertension. Pediatr Pulmonol Suppl 99. 18:201-204. No original data.
Abman S. H. Role of inhaled nitric oxide in treatment of neonatal pulmonary hypertension. Zhongguo Yao Li Xue Bao. 1997;18(6):542-5. No original data. [pmid: 10322917].
Adisesh A., Snashall D. Inhaled nitric oxide. Lancet. 1996;348(9039):1447-8. No original data. [pmid: 8937295].
Ahluwadia J. S., Kelsall A. W. R., Raine J., Rennie J. M., Mahmood M., Oduro A., Latimer R., Pickett J., Higenbottam T. W. Safety of inhaled nitric oxide in premature neonates [6]. ACTA Paediatr. Int. J. Paediatr. 1994;83(3):347-348. No abstractable data. No original data.
Ahluwalia J., Tooley J., Cheema I., Sweet D. G., Curley A. E., Halliday H. L., Field D., Al'malik H., Annamalai S., Midgley P., Hardy P., Tomlin K., Elbourne D. A dose response study of inhaled nitric oxide in hypoxic respiratory failure in preterm infants. Early Hum. Dev. 2006;82(7):477-483. Article does not address any of the Key Questions. [pmid: 16492394].
Aikio O., Saarela T., Pokela M. L., Hallman M. Nitric oxide treatment and acute pulmonary inflammatory response in very premature infants with intractable respiratory failure shortly after birth. Acta Paediatr. Int. J. Paediatr. 2003;92(1):65-69. Article does not address any of the Key Questions. Article address Key Question 1 or 2 ONLY and is not a randomized controlled trial.
Aikio O., Hallman M. Nitric oxide in the acute care of newborns and premature infants: Typpioksidi Vastasyntyneitten ja Keskosten Akuuttihoidossa. Duodecim. 2004;120(15):1853-1858. Unobtainable. [pmid: 15508758].
Alano M. A., Ngougmna E., Ostrea E. M. Jr., Konduri G. G. Analysis of nonsteroidal antiinflammatory drugs in meconium and its relation to persistent pulmonary hypertension of the newborn. Pediatrics. 2001;107(3):519-23. Article does not include infants born at less than 34 weeks gestation. [pmid: 11230592].
Albert Bretons D., Girona Comas J., Casaldaliga Ferrer J., Roqueta Mas J., Perapoch Lopez J., Murtra Ferre M. Transposition of the great arteries and pulmonary hypertension: Inhaled nitric oxide as a therapy and surgical correction: Transposicion de grandes arterias e hipertension pulmonar: Tratamiento con oxido nitrico inhalado y correccion anatomica Precoz. An. Esp. Pediatr. 1997;47(6):633-635. Not written in English and cannot determine eligibility. [pmid: 9575124].
Aly H., Sahni R., Wung J. T. Weaning strategy with inhaled nitric oxide treatment in persistent pulmonary hypertension of the newborn. Arch Dis Child Fetal Neonatal Ed. 1997;76(2):F118-22. Article does not address any of the Key Questions. [pmid: 9135291].
Ambalavanan N., Van Meurs K. P., Perritt R., Carlo W. A., Ehrenkranz R. A., Stevenson D. K., Lemons J. A., Poole W. K., Higgins R. D. Predictors of death or bronchopulmonary dysplasia in preterm infants with respiratory failure. J Perinatol. 2008;28(6):420-6. No abstractable data. [pmid: 18337740].
Andelfinger G., Shirali G. S., Raunikar R. A., Atz A. M. Functional pulmonary atresia in neonatal Marfan's Syndrome: Successful treatment with inhaled nitric oxide. Pediatr. Cardiol. 2001;22(6):525-526. Article does not include infants born at less than 34 weeks gestation. [pmid: 11894162].
Arioni C., Bellini C., Mazzella M., Zullino E., Serra G., Toma P. Congenital right diaphragmatic hernia. Pediatr. Radiol. 2003;33(11):807-808. No original data. Article does not include infants born at less than 34 weeks gestation. [pmid: 12961039].
Ashida Y., Miyahara H., Sawada H., Mitani Y., Maruyama K. Anesthetic management of a neonate with vein of galen aneurysmal malformations and severe pulmonary hypertension. Paediatr. Anaesth. 2005;15(6):525-528. Article does not include infants born at less than 34 weeks gestation. Article does not include pre-term infants who were treated with inhaled nitric oxide. [pmid: 15910357].
Athavale K., Claure N., D'Ugard C., Everett R., Swaminathan S., Bancalari E. Acute effects of inhaled nitric oxide on pulmonary and cardiac function in preterm infants with evolving bronchopulmonary dysplasia. J Perinatol. 2004;24(12):769-74. Article addresses Key Question 1 or 2 ONLY and is not a randomized controlled trial. Other reason. [pmid: 15496967].
Athena IP-H. The effect of inhaled nitric oxide on medical andf functional Outcomes of premature infants at early school-age, American Pediatric Society/SocieTY for Pediatric Research Abstract. 2008. CODEN. RCT. ISSN: CN-00709184. Unobtainable.
Atz A. M., Wessel D. L. Inhaled nitric oxide in the neonate with cardiac disease. Semin Perinatol. 1997;21(5):441-55. Article does not include infants born at less than 34 weeks gestation. Other reason. [pmid: 9352616].
Atz A. M., Wessel D. L. Sildenafil ameliorates effects of inhaled nitric oxide withdrawal. Anesthesiology. 1999;91(1):307-10. Article does not include infants born at less than 34 weeks gestation. Other reason. [pmid: 10422958].
Atz A. M., Munoz R. A., Adatia I., Wessel D. L. Diagnostic and therapeutic uses of inhaled nitric oxide in neonatal Ebstein's Snomaly. Am J Cardiol. 2003;91(7):906-8. Article does not include infants born at less than 34 weeks gestation. Article does not address any of the Key Questions. [pmid: 12667588].
Bagolan P., Casaccia G., Crescenzi F., Nahom A., Trucchi A., Giorlandino C. Impact of a current treatment protocol on outcome of high-risk congenital diaphragmatic hernia. J Pediatr Surg. 2004;39(3):313-8. discussion 313-8. Article does not include infants born at less than 34 weeks gestation. Article does not address any of the Key Questions.
Ballard R., Cnaan Avital, Truog William E., Martin Richard J., Hibbs Anna Maria, Ballard Philip L., Merrill Jeffrey D., Luan Xiangun, Wadlinger Sandra R. The NO CLD Study Group. decreased health services utilization in preterm infants treated with inhaled nitric oxide. Conference Abstracts Online. 2007. CODEN. RCT. ISSN: CN-00709217. Unobtainable.
Ballard P. L., Merrill J. D., Truog W. E., Godinez R. I., Godinez M. H., McDevitt T. M., Ning Y., Golombek S. G., Parton L. A., Luan X., Cnaan A., Ballard R. A. Surfactant function and composition in premature infants treated with ihaled nitric oxide. Pediatrics. 2007;120(2):346-53. No abstractable data. [pmid: 17671061].
Ballard P. L., Truog W. E., Merrill J. D., Gow A., Posencheg M., Golombek S. G., Parton L. A., Luan X., Cnaan A., Ballard R. A. Plasma biomarkers of oxidative stress: relationship to lung disease and inhaled nitric oxide therapy in premature infants. Pediatrics. 2008;121(3):555-61. Article does not address any of the Key Questions. [pmid: 18310205].
Ballard R. A. Inhaled nitric oxide in preterm infants--correction. N Engl J Med. 2007;357(14):1444-5. No abstractable data. [pmid: 17914048].
Balzer DT, Kort HW, Day RW, Corneli HM, Kovalchin JP, Cannon BC, Kaine SF, Ivy DD, Webber SA, Rothman A, Ross RD, Aggarwal S, Takahashi M, Waldman JD. Inhaled Nitric Oxide as a Preoperative Test (INOP Test I): the INOP Test Study Group. Circulation. 2002;106(12 Suppl 1):I76-81. Article does not include infants born at less than 34 weeks gestation. Article does not address any of the Key Questions. [pmid: 12354713].
Banks BA, Pallotto E, Ballard RA. A randomized, double blind, placebo controlled crossover pilot trial of inhaled nitric oxide (iNO) in preterm infants with evolving chronic lung disease (CLD). Pediatric Research. 2001;49(4):284A. No abstractable data.
Baraldi E., Bonetto G., Zacchello F., Filippone M. Low exhaled nitric oxide in school-age children with bronchopulmonary dysplasia and airflow limitation. Am. J. Respir. Crit. Care Med. 2005;171(1):68-72. Article does not address any of the Key Questions. [pmid: 15477497].
Barrington K. J., Finer N. N. Inhaled nitric oxide for preterm infants: a systematic review. Pediatrics. 2007;120(5):1088-99. No original data. [pmid: 17974747].
Barton L. L., Grant K. L., Lemen R. J. Changes in arterial oxygen tension when weaning neonates from inhaled nitric oxide. Pediatr. Pulmonol. 2001;32(1):14-19. Article does not include infants born at less than 34 weeks gestation. [pmid: 11416871].
Bassler D., Choong K., McNamara P., Kirpalani H. Neonatal persistent pulmonary hypertension treated with milrinone: Four case reports. Biol. Neonate. 2006;89(1):1-5. Article does not address any of the Key Questions. [pmid: 16155380].
Beligere N., Rao R. Neurodevelopmental outcome of infants with meconium aspiration syndrome: report of a study and literature review. J Perinatol. 2008;28(Suppl 3):S93-101. Article does not include infants born at less than 34 weeks gestation. [pmid: 19057618].
Bell S. G. The story of nitric oxide: from rascally radical to miracle molecule. Neonatal Netw. 2004;23(4):47-51. No original data. Other reason. [pmid: 15317378].
Benitz W. E., Rhine W. D., Van Meurs K. P., Stevenson D. K. Nitrovasodilator therapy for severe respiratory distress syndrome. J Perinatol. 1996;16(6):443-448. Article does not include pre-term infants who were treated with inhaled nitric oxide. Article does not address any of the Key Questions. [pmid: 8979182].
Benjamin J. T., Hamm C. R., Zayek M., Eyal F. G., Carlson S., Manci E. Acquired Left-Sided Pulmonary Vein Stenosis in an Extremely Premature Infant: A New Entity?. J. Pediatr. 2009;154(3):459-459.e1. Article does not address any of the Key Questions. Other reason. [pmid: 19874765].
Benjamin J. T. Practice and guidelines. Pediatrics. 1996;97(4):604-605. No original data. Article does not include infants born at less than 34 weeks gestation. [pmid: 8632960].
Betremieux P., Gaillot T., De La Pintiere A., Beuchee A., Pasquier L., Habonimana E., Le Bouar G., Branger B., Milon J., Fremond B., Wodey E., Odent S., Poulain P., Pladys P. Congenital diaphragmatic hernia: Prenatal diagnosis permits immediate intensive care with high survival rate in isolated cases. A population-based study. Prenat. Diagn. 2004;24(7):487-493. Article does not include infants born at less than 34 weeks gestation. [pmid: 15300735].
Bhutani V. K., Chima R., Sivieri E. M. Innovative neonatal ventilation and meconium aspiration syndrome. Indian J Pediatr. 2003;70(5):421-7. Article does not include infants born at less than 34 weeks gestation. [pmid: 12841404].
Biban P., Trevisanuto D., Pettenazzo A., Ferrarese P., Baraldi E., Zacchello F. Inhaled nitric oxide in hypoxaemic newborns who are candidates for extracorporeal life support. Eur. Respir. J. 1998;11(2):371-376. Article does not include infants born at less than 34 weeks gestation. [pmid: 9551741].
Bland R. D. Inhaled nitric oxide: A premature remedy for chronic lung disease?. Pediatrics. 1999;103(3):667-670. No original data. [pmid: 10049974].
Bohnhorst B., Poets C., Freihorst J. Inhaled nitric oxide in severe bronchopulmonary dysplasia: Inhalatives stickstoffmonoxid in der therapie der schweren bronchopulmonalen dysplasie. Monatsschr. Kinderheilkd. 2001;149(7):686-690. Not written in English and cannot determine eligibility.
Boloker J., Bateman D. A., Wung J.-T., Stolar C. J. H. Congenital diaphragmatic hernia in 120 infants treated consecutively with permissive hypercapnea/spontaneous respiration/elective repair. J. Pediatr. Surg. 2002;37(3):357-366. Article does not include infants born at less than 34 weeks gestation. Article does not address any of the Key Questions. [pmid: 11877648].
Booth G. R., Thornton K., Jureidini S., Fleming R. E. Subendocardial infarction associated with ventricular hypertrophy in preterm infants with chronic lung disease. J. Perinatol. 2008;28(8):580-583. Article does not address any of the Key Questions. [pmid: 18668110].
Bouchet M., Renaudin M.-H., Raveau C., Mercier J.-C., Dehan M., Zupan V. Safety requirement for use of inhaled nitric oxide in neonates [25]. LANCET. 1993;341(8850):968-969. No human data included. Other reason. [pmid: 8096310].
Braschi A., Iannuzzi M., Belliato M., Iotti G. A. Therapeutic use of nitric oxide in critical settings. Monaldi Arch Chest Dis. 2001;56(2):177-9. No original data. [pmid: 11499314].
Bruckheimer E., Bulbul Z., Pinter E., Gailani M., Kleinman C. S., Fahey J. T. Inhaled nitric oxide therapy in a critically ill neonate with Ebstein's anomaly. Pediatr. Cardiol. 1998;19(6):477-479. Article does not include infants born at less than 34 weeks gestation. [pmid: 9770576].
Burchfield D. J., Blackmon L. R., Barrington K. J. Postnatal steroids to treat or prevent chronic lung disease in preterm infants [4] (multiple letters). Pediatrics. 2003;111(1):221-222. No original data. [pmid: 12509584].
Cavallaro G., Agazzani E., Andaloro L., Bottura C., Cristofori G., Mussini P., Sacco F., Compagnoni G. [Sildenafil and nitric oxide inhalation in neonatal pulmonary hypertension. Three case reports]. Pediatr Med Chir. 2008;30(3):149-55. Not written in English and cannot determine eligibility. [pmid: 19024859].
Channick R. N., Rubin L. J. Combination therapy for pulmonary hypertension: a glimpse into the future?. Crit Care Med. 2000;28(3):896-7. No original data. [pmid: 10752856].
Chaudhari M., Vogel M., Wright C., Smith J., Haworth S. G. Sildenafil in neonatal pulmonary hypertension due to impaired alveolarisation and plexiform pulmonary arteriopathy. Arch Dis Child Fetal Neonatal Ed. 2005;90(6):F527-8. Article does not include infants born at less than 34 weeks gestation. [pmid: 16244212].
Cheifetz I. M. Inhaled nitric oxide: plenty of data, no consensus. Crit Care Med. 2000;28(3):902-3. No original data. [pmid: 10752860].
Cheung P. Y., Etches P. C., Radomski M. W. NO effect on hemostasis. J Pediatr. 1999;134(3):383-4. No original data. Article address Key Question 1 or 2 ONLY and is not a randomized controlled trial. [pmid: 10064685].
Cheung P.-Y., Salas E., Etches P. C., Phillipos E., Schulz R., Radomski M. W. Inhaled nitric oxide and inhibition of platelet aggregation in critically ill neonates. Lancet. 1998;351(9110):1181-1182. Article address Key Question 1 or 2 ONLY and is not a randomized controlled trial. Other reason. [pmid: 9643700].
Christopher Rhee, Sudhir Sriram, Michael Schreiber, William Meadow. Pediatrics University of Chicago Chicago IL. Effects of Inhaled Nitric Oxide on Cardiac Output Using Point-Of-Care Bedside Echocardiography in Preterm Infants. PASAbstracts. 2009;#volume#:#startpage#. Article does not address any of the Key Questions. No abstractable data.
Christou H., Adatia I., Van Marter L. J., Kane J. W., Thompson J. E., Stark A. R., Wessel D. L., Kourembanas S. Effect of inhaled nitric oxide on endothelin-1 and cyclic guanosine 5'- monophosphate plasma concentrations in newborn infants with persistent pulmonary hypertension. J. PEDIATR. 1997;130(4):603-611. Article does not include infants born at less than 34 weeks gestation. [pmid: 9108859].
Christou H., Magnani B., Morse D. S., Allred E. N., Van Marter L. J., Wessel D. L., Kourembanas S. Inhaled nitric oxide does not affect adenosine 5'-diphosphate-dependent platelet activation in infants with persistent pulmonary hypertension of the newborn. Pediatrics 98. 102(6):1390-1393. Article does not include infants born at less than 34 weeks gestation.
Claire-Marie Loys. Delphine Maucort-Boulch Guy Putet Stephane Hays. Neonatologie Hopital de la Croix Rousse Hospices Civils de Université Claude Bernard Lyon France and Biostatistique, Hopital Lyon Sud Hospices Civils de Lyon Université Claude Bernard Lyon France.. Early Risk Factors for Death or Severe Brain Lesions in Extremely Low Birth Weight Preterm Infants. PASAbstracts. 2009;#volume#:#startpage#. Article does not include pre-term infants who were treated with inhaled nitric oxide. No abstractable data.
Clark R. H., Bloom B. T., Spitzer A. R., Gerstmann D. R. Reported medication use in the neonatal intensive care unit: data from a large national data set. Pediatrics. 2006;117(6):1979-1987. Article does not address any of the Key Questions. Other reason. [pmid: 16740839].
Concheiro Guisan A., Sousa Rouco C., Suarez Traba B., Paradela Carreira A., Ocampo Cardalda S., Antelo Cortizas J. Inhaled iloprost: A therapeutic alternative for persistent pulmonary hypertension of the newborn [1]: Iloprost inhalado: Una alternativa terapeutica para la hipertension pulmonar persistente del recien nacido. An. Pediatr. 2005;63(2):175-176. Not written in English and cannot determine eligibility. Article does not include pre-term infants who were treated with inhaled nitric oxide.
Cornfield D. N., Abman S. H. Inhalational nitric oxide in pulmonary parenchymal and vascular disease. J Lab Clin Med. 1996;127(6):530-9. No original data. Other reason. [pmid: 8648257].
Cui X., Quezado Z. M. N., Eichacker P. Q. Inhaled nitric oxide: Is systemic host defense at risk?. Crit. Care Med. 2002;30(4):945-946. No original data. Article does not address any of the Key Questions. [pmid: 11940783].
Dahlheim M., Witsch M., Demirakca S., Lorenz C., Schaible T. Congenital diaphragmatic hernia - Results of an ECMO-centre: Angeborene zwerchfellhernie - Ergebnisse eines ECMO-zentrums. Klin. Padiatr. 2003;215(4):213-222. Not written in English and cannot determine eligibility. [pmid: 12929011].
Dani C., Bertini G., Rubaltelli F. F. Inhaled nitric oxide. N Engl J Med. 2005;353(15):1626-8. author reply 1626-8. No abstractable data. [pmid: 16221790].
Datin-Dorriere V., Rouzies S., Taupin P., Walter-Nicolet E., Benachi A., Sonigo P., Mitanchez D. Prenatal prognosis in isolated congenital diaphragmatic hernia. Am J Obstet Gynecol. 2008;198(1):80.e1-5. Article does not address any of the Key Questions. [pmid: 18166314].
Datin-Dorriere V., Walter-Nicolet E., Rousseau V., Taupin P., Benachi A., Parat S., Hubert P., Revillon Y., Mitanchez D. Experience in the management of eighty-two newborns with congenital diaphragmatic hernia treated with high-frequency oscillatory ventilation and delayed surgery without the use of extracorporeal membrane oxygenation. J. Intensive Care Med. 2008;23(2):28-135. Other reason.
Davis C. F., Sabharwal A. J. Management of congenital diaphragmatic hernia. Arch Dis Child Fetal Neonatal Ed. 1998;79(1):F1-3. No original data. [pmid: 9797617].
Day R. W., Lynch J. M., White K. S., Ward R. M. Acute response to inhaled nitric oxide in newborns with respiratory failure and pulmonary hypertension. Pediatrics. 1996;98(4 Pt 1):698-705. Article does not include infants born at less than 34 weeks gestation. Article does not address any of the Key Questions. [pmid: 8885949].
Day R. W. Cerebral blood flow velocity acutely decreases in newborns who respond to inhaled nitric oxide. Am. J. Perinatol. 2001;18(4):185-194. Article does not address any of the Key Questions. Article address Key Question 1 or 2 ONLY and is not a randomized controlled trial. [pmid: 11444362].
Day R. W. Inhaled nitric oxide prevents severe hypoxemia in newborns with acute lung disease and pulmonary hypertension. Pediatrics. 1998;101(6):1093-4. Article does not include infants born at less than 34 weeks gestation. [pmid: 9614429].
Day R. W. Right ventricular size is acutely decreased by inhaled nitric oxide in newborns with pulmonary hypertension. Am J Perinatol. 1998;15(7):445-51. Article does not include infants born at less than 34 weeks gestation. Article does not address any of the Key Questions. [pmid: 9759913].
De Groote K, Van Overmeire B. Inhaled nitric oxide as treatment of persistent pulmonary hypertension in newborns: A review. INHALATIE VAN STIKSTOFMONOXIDE ALS BEHANDELING VAN PERSISTERENDE PULMONALE HYPERTENSIE BIJ DE PASGBORENE. EEN OVERZICHT. Tijdschr. Geneeskd. 1998;54(12):817-823. Not written in English and cannot determine eligibility.
De Luca D., Zecca E., Vento G., De Carolis M. P., Romagnoli C. Transient effect of epoprostenol and sildenafil combined with iNO for pulmonary hypertension in congenital diaphragmatic hernia [2]. Paediatr. Anaesth. 2006;16(5):597-598. Article does not include infants born at less than 34 weeks gestation. [pmid: 16677275].
Di Fiore J. M., Hibbs A. M., Zadell A. E., Merrill J. D., Eichenwald E. C., Puri A. R., Mayock D. E., Courtney S. E., Ballard R. A., Martin R. J. The effect of inhaled nitric oxide on pulmonary function in preterm infants. J Perinatol. 2007;27(12):766-71. No abstractable data. [pmid: 17805339].
Dimitriou G., Greenough A., Kavvadia V., Devane S. P., Rennie J. M. Outcome predictors in nitric oxide treated preterm infants. Eur. J. Pediatr. 1999;158(7):589-591. No abstractable data. [pmid: 10412821].
Dobyns E. L., Anas N. G., Fortenberry J. D., Deshpande J., Cornfield D. N., Tasker R. C., Liu P., Eells P. L., Griebel J., Kinsella J. P., Abman S. H. Interactive effects of high-frequency oscillatory ventilation and inhaled nitric oxide in acute hypoxemic respiratory failure in pediatrics. Crit. Care Med. 2002;30(11):2425-2429. Article does not address any of the Key Questions. [pmid: 12441749].
Dobyns E. L., Griebel J., Kinsella J. P., Abman S. H., Accurso F. J. Infant lung function after inhaled nitric oxide therapy for persistent pulmonary hypertension of the newborn. Pediatr Pulmonol. 1999;28(1):24-30. Article does not include infants born at less than 34 weeks gestation. [pmid: 10406047].
Dominguez E. D., Vasallo J. C., Berrueta M., Acosta L., Gaivironsky R., Polack N. High frequency ventilation and inhaled nitric oxide in pediatrics and neonatology: Avances en terapia intensiva neonatal y pediatrica. Ventilacion de alta frecuencia administracion de oxido nitrico inhalatorio. Prensa Med. Argent. 1998;85(7):823-827. Not written in English and cannot determine eligibility.
Drinkwater D. C. Jr., Aharon A. S., Quisling S. V., Dodd D., Reddy V. S., Kavanaugh-McHugh A., Doyle T., Patel N. R., Barr F. E., Kambam J. K., Graham T. P., Chang P. A. Modified norwood operation for hypoplastic left heart syndrome. Ann. Thorac. Surg. 2001;72(6):2081-2087. Article does not address any of the Key Questions. [pmid: 11789798].
Drury J. A., Nycyk J. A., Subhedar N. V., Shaw N. J., Cooke R. W. Inhaled nitric oxide does not increase lipid peroxidation in preterm infants. Eur J Pediatr. 1998;157(12):1033. No abstractable data. [pmid: 9877048].
Du L.-Z., Shi L.-P., Sun M.-Y., Zhou B.-H., Chen C., Shao X.-M., Zhang X.-D., Lu Y., Sun B. Inhaled nitric oxide in preterm and term neonates with hypoxemic respiratory failure and persistent pulmonary hypertension. Acta Pharmacol. Sin. 2002;23(SUPPL.):69-73. No abstractable data.
Dubois A., Storme L., Jaillard S., Truffert P., Riou Y., Rakza T., Pierrat V., Gottrand F., Pruvot F. R., Leclerc F., Lequien P. Congenital diaphragmatic hernia: Retrospective study of 123 cases: Les hernies congenitales des coupoles diaphragmatiques. Etude retrospective de 123 observations recueillies dans le service de medecine neonatale du CHRU de Lille entre 1985 et 1996. Arch. Pediatr. 2000;7(2):132-142. Not written in English and cannot determine eligibility. [pmid: 10701057].
Dursun S. M., Robertson H. Nitric oxide in neonates. Lancet. 2000;356(9237):1274-5. No original data. Article does not include infants born at less than 34 weeks gestation. [pmid: 11072973].
Duval E. L. I. M., Leroy P. L. J. M., Gemke R. J. B. J., Van Vught A. J. High-frequency oscillatory ventilation in RSV bronchiolitis patients. Respir. Med. 1999;93(6):435-440. Article does not address any of the Key Questions. Article address Key Question 1 or 2 ONLY and is not a randomized controlled trial. [pmid: 10464828].
Dweik R. A. The promise and reality of nitric oxide in the diagnosis and treatment of lung disease. Cleve Clin J Med. 2001;68(6):486. 488. 490. 493. No original data. [pmid: 11405609].
Easa D., Murai D. T., Oka B., Dressel M., Vanderford P., Pelke S., Balaraman V. Early experience with inhaled nitric oxide for the treatment of infants and children with pulmonary hypertension. Hawaii Med J. 1996;55(4):67-9. Article does not include infants born at less than 34 weeks gestation. [pmid: 8935980].
Ehlen M., Wiebe B. Iloprost in persistent pulmonary hypertension of the newborn. Cardiol Young. 2003;13(4):361-363. Article does not include infants born at less than 34 weeks gestation. Article does not address any of the Key Questions. [pmid: 14694957].
Ehrenkranz R. A. Inhaled nitric oxide and treatment of hypoxic respiratory failure. Zhongguo Yao Li Xue Bao. 1997;18(6):546-7. Article does not include infants born at less than 34 weeks gestation. [pmid: 10322918].
Ellington M. Jr., O'Reilly D., Allred E. N., McCormick M. C., Wessel D. L., Kourembanas S. Child health status, neurodevelopmental outcome, and parental satisfaction in a randomized, controlled trial of nitric oxide for persistent pulmonary hypertension of the newborn. Pediatrics. 2001;107(6):1351-1356. Article does not include infants born at less than 34 weeks gestation. [pmid: 11389256].
Ergenekon E. Inhaled nitric oxide in premature infants. J Pediatr. 1998;132(2):375. No original data. [pmid: 9506664].
Etches P. C., Finer N. N., Ehrenkranz R. A., Wright L. L. Clinical monitoring of inhaled nitric oxide. Pediatrics. 1995;95(4):620-1. No original data. Article does not address any of the Key Questions. [pmid: 7700777].
Favilli S., De Simone L., Pollini I., Bettuzzi M. G., Cianfrini D., Crepaz R., Santillo V., Trevisanuto D., Vignati G., Manetti A. Persistent pulmonary hypertension in newborns: Prevalence and clinical and echocardiographic features. A multicentric study: Prevalenza e caratteristiche della ipertensione polmonare persistente del neonato. Studio multicentrico. G. Ital. Cardiol. 1998;28(11):1247-1252. Article does not include pre-term infants who were treated with inhaled nitric oxide. Article does not address any of the Key Questions. [pmid: 9866802].
Field D., Elbourne D. Use of inhaled nitric oxide to improve oxygenation in the neonate [4]. Arch. Dis. Child. Fetal Neonatal Ed. 2000;82(3):F258-F259. No original data. [pmid: 10885938].
Field D., Normand C., Elbourne D. Cost-effectiveness of inhaled nitric oxide in the treatment of neonatal respiratory failure in the US. Pediatrics. 2003;112(6 Pt 1):1422-3. No original data. Article does not address any of the Key Questions. [pmid: 14654622].
Field D. Trials of nitric oxide. Biol. Neonate. 2003;84(1):103-104. No original data. [pmid: 12890946].
Figueras Aloy J., Sorni Hubrecht A., Botet Moussons F., Rodriguez Miguelez J. M., Jimenez Gonzalez R. [The immediate response to the administration of inhaled nitric oxide in a newborn infant with congenital diaphragmatic hernia and pulmonary hypertension]. An Esp Pediatr. 1996;44(1):70-2. Not written in English and cannot determine eligibility. [pmid: 8849068].
Figueras-Aloy J., Gomez L., Rodriguez-Miguelez J. M., Jordan Y., Salvia M. D., Jimenez W., Carbonell-Estrany X. Plasma nitrite/nitrate and endothelin-1 concentrations in neonatal sepsis. Acta Paediatr. Int. J. Paediatr. 2003;92(5):582-587. Article does not include pre-term infants who were treated with inhaled nitric oxide. Article does not address any of the Key Questions.
Finer N. N. Inhaled nitric oxide for preterm infants: a therapy in search of an indication? The search continues. J Pediatr. 2005;146(3):301-3. No original data. [pmid: 15756205].
Firth A. L., Yuan J. X. Bringing down the ROS: a new therapeutic approach for PPHN. Am J Physiol Lung Cell Mol Physiol. 2008;295(6):L976-8. No original data. [pmid: 18931050].
Fletcher G., Daniel M. Problems in assessing the effect of nebulized prostacyclin in patients whose lungs are ventilated. Anesthesiology. 1996;84(1):242-3. No original data. [pmid: 8572349].
Flieger K. The benefit of nitric oxide inhalation in premature infants is disputed: Nutzen der NO-inhalation bei fruhgeborenen umstritten. Geburtshilfe Frauenheilkd. 2006;66(3):216. Not written in English and cannot determine eligibility.
Fraisse A., Geva T., Gaudart J., Wessel D. L. Predictive factors of Doppler echocardiography in persistent pulmonary artery hypertension of the neonate: Facteurs predictifs de l'echocardiographie-Doppler dans l'hypertension arterielle pulmonaire persistante du nouveaune. Arch. Mal. Coeur Vaiss. 2004;97(5):501-506. Not written in English and cannot determine eligibility. Article does not include infants born at less than 34 weeks gestation. [pmid: 15214555].
Fredly S., Aksnes G., Viddal K. O., Lindemann R., Fugelseth D. The outcome in newborns with congenital diaphragmatic hernia in a Norwegian region. Acta Paediatr. 2009;98(1):107-11. Article does not include infants born at less than 34 weeks gestation. Other reason. [pmid: 18795908].
Frenckner B. Congenital diaphragmatic hernia. INT. J. ARTIF. ORGANS. 1995;18(10):579-583. No original data. Article does not address any of the Key Questions. [pmid: 8647587].
Frostell C. G., Lonnqvist P. A., Sonesson S. E., Gustafsson L. E., Lohr G., Noack G. Near fatal pulmonary hypertension after surgical repair of congenital diaphragmatic hernia. Successful use of inhaled nitric oxide. Anaesthesia. 1993;48(8):679-83. Article does not include infants born at less than 34 weeks gestation. [pmid: 8214457].
Frostell C. G. Clinical aspects of nitric oxide and surfactant replacement. Biol Neonate. 1997;71(Suppl 1):39-43. No original data. [pmid: 9209749].
Frostell C. G. Nitric oxide and acute respiratory failure. Monaldi Arch Chest Dis. 1996;51(6):538-42. No original data. [pmid: 9046170].
Fujikawa S., Yang L., Waffarn F., Lerner M. Persistent pulmonary hypertension of the newborn (PPHN) treated with inhaled nitric oxide: preliminary hearing outcomes. J Am Acad Audiol. 1997;8(4):263-8. quiz 297. Article does not include infants born at less than 34 weeks gestation. [pmid: 9272748].
Gaio G., Santoro G., Esposito R., Bianco G., Giliberti P., Russo M. G., Calabro R. Patent ductus arteriosus 'stenting' as a life-saving approach in severe neonatal Ebstein's anomaly. J Cardiovasc Med (Hagerstown). 2007;8(11):937-9. Article does not include infants born at less than 34 weeks gestation. [pmid: 17906480].
Gao X. R., Wu Y. Q., Li L. [Clinical analysis of chronic lung disease in preterm infants]. Zhongguo Dang Dai Er Ke Za Zhi. 2008;10(4):539-40. Not written in English and cannot determine eligibility. [pmid: 18706185].
Gao X. R., Wu Y. Q., Peng X. M., Huang M., Liu X. H. Inhaled nitric oxide for newborn infants with severe respiratory failure. Zhongguo Dang Dai Er Ke Za Zhi. 2006;8(2):155-157. Not written in English and cannot determine eligibility. [pmid: 16613714].
Gaston B., Keith J. F. 3rd. Nitric oxide and bleeding time. Pediatrics 94. 94(1):134-5. No original data. Gaston B., Keith J. F. III, Kinsella J. P., Abman S. H. Nitric oxide and bleeding time [4]. PEDIATRICS. 1994;94(1):134-135. No original data. Article does not address any of the Key Questions. [pmid: 8008529].
Geary C., Whitsett J. Inhaled nitric oxide for oligohydramnios-induced pulmonary hypoplasia: A report of two cases and review of the literature. J. Perinatol. 2002;22(1):82-85. Article does not address any of the Key Questions. [pmid: 11840249].
Geggel R. L. Inhalational nitric oxide: a selective pulmonary vasodilator for treatment of persistent pulmonary hypertension of the newborn. J Pediatr. 1993;123(1):76-9. No original data. [pmid: 8320629].
George T. N., Johnson K. J., Bates J. N., Segar J. L. The effect of inhaled nitric oxide therapy on bleeding time and platelet aggregation in neonates. J. Pediatr. 1998;132(4):731-734. Article does not include infants born at less than 34 weeks gestation. Article does not address any of the Key Questions. [pmid: 9580780].
Gessler P., Nebe T., Birle A., Mueller W., Kachel W. A new side effect of inhaled nitric oxide in neonates and infants with pulmonary hypertension: Functional impairment of the neutrophil respiratory burst. INTENSIVE CARE MED. 1996;22(3):252-258. Article does not include infants born at less than 34 weeks gestation. Article address Key Question 1 or 2 ONLY and is not a randomized controlled trial. [pmid: 8727441].
Gewillig M., Brown S. C., De Catte L., Debeer A., Eyskens B., Cossey V., Van Schoubroeck D., Van Hole C., Devlieger R. Premature foetal closure of the arterial duct: Clinical presentations and outcome. Eur. Heart J. 2009;30(12):1530-1536. Article does not address any of the Key Questions. [pmid: 19389789].
Gin-Mestan KK, Srisuparp P, Carlson AD, Thomas G, Lee G, Marks JD, Schreiber MD. Inhaled nitric oxide improves oxygenation in premature infants with respiratory distress syndrome: preliminary results of a prospective, randomized trial. Pediatric research. 2002;51(4):348A. No abstractable data.
Gin-Mestan KK, Troyke S, Lee G, Hecox KE, Schreiber MD. Improved neurodevelopmental outcome at one year in premature infants treated with inhaled nitric oxide: preliminary results of a prospective, randomized trial. Pediatric research. 2002;51(4):405A. No abstractable data.
Goldman A. P., Tasker R. C., Cook P., Macrae D. J. Transfer of critically ill patients with inhaled nitric oxide. Arch Dis Child. 1995;73(5):480. Article does not include infants born at less than 34 weeks gestation. [pmid: 8554374].
Golzand E., Bar-Oz B., Arad I. Intravenous prostacyclin in the treatment of persistent pulmonary hypertension of the newborn refractory to inhaled nitric oxide. Isr Med Assoc J. 2005;7(6):408-9. Article does not include infants born at less than 34 weeks gestation. [pmid: 15984391].
Gonzalez A., Fabres J., D'Apremont I., Urcelay G., Avaca M., Gandolfi C., Kattan J. Randomized controlled trial of early compared with delayed use of inhaled nitric oxide in newborns with a moderate respiratory failure and pulmonary hypertension. J. Perinatol. 2009:#startpage#. Article does not include infants born at less than 34 weeks gestation.
Gorrotxategi Gorrotxategi P., Eizaguirre Sexmilo I., Iturrioz Mata A., Miranda Abejon G., Collado Espina V., Birritxinaga Gaztelurrutia B. [Use of nitric oxide in a newborn child with pulmonary cystic adenomatoid malformation]. Cir Pediatr. 2000;13(1):35-8. Not written in English and cannot determine eligibility. No abstractable data. [pmid: 12602021].
Gortner L. Neonatal intensive care medicine: Neonatologische intensivmedizin. Arzneim.-Forsch. Drug Res. 2004;54(11):781-782. Not written in English and cannot determine eligibility.
Gothberg S., Edberg K. E., Tang S. F., Michelsen S., Winberg P., Holmgren D., Miller O., Thaulow E., Lonnqvist P. A. Residual pulmonary hypertension in children after treatment with inhaled nitric oxide: a follow-up study regarding cardiopulmonary and neurological symptoms. Acta Paediatr. 2000;89(12):1414-9. Article does not include infants born at less than 34 weeks gestation. Other reason. [pmid: 11195228].
Graham E. M., Bradley S. M., Atz A. M. Preoperative management of hypoplastic left heart syndrome. Expert Opin. Pharmacother. 2005;6(5):687-693. No original data. [pmid: 15934895].
Greenough A. Respiratory support techniques for prematurely born infants: new advances and perspectives. Acta Paediatr Taiwan. 2001;42(4):201-6. No original data. [pmid: 11550407].
Gressens P., Rogido M., Paindaveine B., Sola A. The impact of neonatal intensive care practices on the developing brain. J Pediatr. 2002;140(6):646-53. No original data. [pmid: 12072865].
Gupta A., Rastogi S., Sahni R., Bhutada A., Bateman D., Rastogi D., Smerling A., Wung J. T. Inhaled nitric oxide and gentle ventilation in the treatment of pulmonary hypertension of the newborn--a single-center, 5-year experience. J Perinatol. 2002;22(6):435-41. Article does not include infants born at less than 34 weeks gestation. Other reason. [pmid: 12168118].
Guthrie S. O., Walsh W. F., Auten K., Clark R. H. Initial dosing of inhaled nitric oxide in infants with hypoxic respiratory failure. J Perinatol. 2004;24(5):290-4. Article does not include infants born at less than 34 weeks gestation. [pmid: 15042110].
Hallman M., Aikio O. Nitric oxide in critical respiratory failure of very low birth weight infants. Paediatr. Respir. Rev. 2004;5(SUPPL. A):S249-S252. No original data. [pmid: 14980280].
Hamon I, Schroeder H, Buchweiller MC, Franck P, Nicolas MB, Fresson J, Dousset B, Nabet P, Hascoet JM. Early effect of inhaled nitric oxide (iNO) on the oxidative balance in 23-32 weeks gestation infants: preliminary data from a randomized controlled trial. Pediatric Research. 2001;49(4):266A. No abstractable data.
Hanna MG, Shaltout FF, El-Fikky MA, Gamal H. Assessment of the role of inhaled nitric oxide and high frequency oscillatory ventilation in persistent pulmonary hypertension of the newborn. Egyptian Journal of Anaesthesia. 2004;20(1):47-52. CODEN. CCT. ISSN: CN-00515709. Unobtainable.
Hancock Friesen C. L., Zurakowski D., Thiagarajan R. R., Forbess J. M., del Nido P. J., Mayer J. E., Jonas R. A. Total anomalous pulmonary venous connection: an analysis of current management strategies in a single institution. Ann Thorac Surg. 2005;79(2):596-606. discussion 596-606. Other reason.
Hansen T. W. R. Nitric oxide in the treatment of oxygenation difficulties in neonates: Nitrogenoksid I Behandlingen Av Oksygeneringssvikthos Nyfodte. Tidsskr. Nor. Laegeforen. 1995;115(28):3493-3495. Not written in English and cannot determine eligibility. [pmid: 7491601].
Haruda F. D., Volpe J. J. The structure of blood vessels in the germinal matrix and the autoregulation of cerebral blood flow in premature infants [6]. Pediatrics. 2001;108(4):1050. No original data. No human data included. [pmid: 11589213].
Heal C. A., Spencer S. A. Methaemoglobinaemia with high-dose nitric oxide administration. Acta Paeddtr. Int. J. Paediatr. 1995;84(11):1318-1319. Article does not include infants born at less than 34 weeks gestation.
Henneberg S. W., Jepsen S., Andersen P. K., Pedersen S. A. Inhalation of nitric oxide as a treatment of pulmonary hypertension in congenital diaphragmatic hernia. J. Pediatr. Surg. 1995;30(6):853-855. Article does not include infants born at less than 34 weeks gestation. [pmid: 7666321].
Henrichsen T., Goldman A. P., Macrae D. J. Inhaled nitric oxide can cause severe systemic hypotension. J Pediatr. 1996;129(1):18.3. Article does not include infants born at less than 34 weeks gestation.
Hering F. Congress report on the 29th Neonatal and Infant Respiratory Symposium in Vail, February 13th to 16th, 2002:. Kongressbericht uber das 29. Neonatal und Infant Respiratory Symposium in Vail, 13. bis 16. Februar 2002. Anasthesiol. Intensivmed. Notf.med. Schmerzther. 2002;37(8):496-500. Not written in English and cannot determine eligibility.
Herkenhoff M., Schaible T., Reiss I., Kandzora J., Moller J., Gortner L. Persistent pulmonary hypertension of the newborn and preterm infant: Selective pulmonary vasodilatation with inhalational nitric oxide (iNO): Persistierende pulmonale hypertension (PPHN) im fruh- und neugeborenenalter: Selektive pulmonale vasodilatation mit inhalativem stickstoffmonoxid (iNO). Z. Geburtshilfe Neonatol. 1998;202(1):25-29. Not written in English and cannot determine eligibility. [pmid: 9577919].
Hintz S. R., Benitz W. E., Halamek L. P., Van Meurs K. P., Rhine W. D. Secondary infection presenting as recurrent pulmonary hypertension. J Perinatol. 2000;20(4):262-4. Article does not include infants born at less than 34 weeks gestation. [pmid: 10879342].
Hoehn T., Gratopp A., Raehse K., Koehne P. Effects of hyperoxia and nitric oxide on endogenous nitric oxide production in polymorphonuclear leukocytes. Neonatology. 2008;94(2):132-137. Article does not include infants born at less than 34 weeks gestation. Article does not address any of the Key Questions. [pmid: 18332642].
Hoehn T., Krause M., Wildberg A., Pringsheim W., Leititis J. U. [Reversal of a right-left shunt and permanent improvement of oxygenation by inhalation of nitrogen monoxide in a premature infant with lung hypoplasia and asphyxia]. Z Geburtshilfe Neonatol. 1997;201(3):105-7. Not written in English and cannot determine eligibility. [pmid: 9303782].
Hoffman G. M., Nelin L. D. Mean airway pressure and response to inhaled nitric oxide in neonatal and pediatric patients. Lung. 2005;183(6):441-53. Article does not include infants born at less than 34 weeks gestation. [pmid: 16465603].
Hohn T., Schiffer B. Treatment of persistent pulmonary hypertension of the newborn by nitrogen monoxide inhalation: Die Behandlung der persistierenden pulmonalen Hypertonie des Neugeborenen mit inhalativem Stickstoffmonoxid (iNO). Kinderkrankenschwester. 1997;16(10):422-424. Not written in English and cannot determine eligibility. [pmid: 9397790].
Holmer Fiori H., Machado Fiori R. Nitric oxide in persistent pulmonary hypertension of the newborn: Oxido nitrico na hipertensao pulmonar persistente do recemnascido. J. PEDIATR. 96. 72(3):121-122. Not written in English and cannot determine eligibility.
Hoo A.-F., Beardsmore C. S., Castle R. A., Ranganathan S. C., Tomlin K., Field D., Elbourne D., Stocks J. Respiratory function during infancy in survivors of the INNOVO trial. Pediatr. Pulmonol. 2009;44(2):155-16.1. No abstractable data. [pmid: 19148936].
Hoshi M., Suzumura H., Nitta A., Tsuboi Y., Tsuboi T., Inoue H., Tanaka G., Arisaka O. Treatment of persistent pulmonary hypertension of the newborn. Dokkyo J. Med. Sci. 2002;29(1):119-124. Article does not include pre-term infants who were treated with inhaled nitric oxide.
Hosono S., Ohno T., Kimoto H., Shimizu M., Takahashi S., Harada K. Developmental outcomes in persistent pulmonary hypertension treated with nitric oxide therapy. Pediatr Int. 2009;51(1):79-83. Article does not include infants born at less than 34 weeks gestation. [pmid: 19371283].
Hosono S., Ohno T., Kimoto H., Shimizu M., Takahashi S., Harada K. Inhaled nitric oxide therapy might reduce the need for hyperventilation therapy in infants with persistent pulmonary hypertension of the newborn. J. Perinat. Med. 2006;34(4):333-337. Article does not include infants born at less than 34 weeks gestation. [pmid: 16856826].
Hsieh W. S. Role of nitric oxide in neonatal diseases. Acta Paediatr Taiwan. 2002;43(3):122-3. No original data. [pmid: 12148959].
Hsieh W.-S. Meconium-stained amniotic fluid, meconium aspiration syndrome, and persistent pulmonary hypertension of the newborn. Acta Paediatr. Taiwan. 2004;45(4):197-199. No original data. [pmid: 15624362].
Hsu H. T., Lin J. Y., Tseng H. I., Chang Y. L., Yu K. L., Cheng K. I., Tang C. S. Total intravenous anesthesia for repair of congenitral diaphragmatic hernia: a case report. Kaohsiung J Med Sci. 2004;20(9):465-9. Article does not include infants born at less than 34 weeks gestation. [pmid: 15506561].
Hsu H.-Y., Huang C.-B., Chen C.-C., Huang H.-C., Liu C.-A., Chung M.-Y. The therapeutic effect of inhaled nitric oxide in neonatal persistent pulmonary hypertension with and without Congenital Heart Disease. Clin. Neonatol. 2006;13(1):1-5. Article does not include infants born at less than 34 weeks gestation. Other reason.
Hui T. T., Danielson P. D., Anderson K. D., Stein J. E. The impact of changing neonatal respiratory management on extracorporeal membrane oxygenation utilization. J. Pediatr. Surg. 2002;37(5):703-705. Article does not include infants born at less than 34 weeks gestation. [pmid: 11987082].
Hutchin M. E., Gilmer C., Yarbrough W. G. Delayed-onset sensorineural hearing loss in a 3-year-old survivor of persistent pulmonary hypertension of the newborn. Arch. Otolaryngol. Head Neck Surg. 2000;126(8):1014-1017. Article does not include infants born at less than 34 weeks gestation. [pmid: 10922237].
Hwang S. J., Lee K. H., Hwang J. H., Choi C. W., Shim J. W., Chang Y. S., Park W. S. Factors affecting the response to inhaled nitric oxide therapy in persistent pulmonary hypertension of the newborn infants. Yonsei Med J. 2004;45(1):49-55. Article does not include infants born at less than 34 weeks gestation. [pmid: 15004868].
Ibrahim TS, El-Mohamady HS. Inhaled nitric oxide and prone position: How far they can improve oxygenation in pediatric patients with acute respiratory distress syndrome?. Journal of Medical Sciences. 2007;7(3):390-5. Article does not include infants born at less than 34 weeks gestation. Article does not address any of the Key Questions.
Ichiba H., Fujioka H., Saitoh M., Shintaku H. Neonatal listeriosis with severe respiratory failure responding to nitric oxide inhalation. Pediatr Int. 2000;42(6):696-8. Article does not include infants born at less than 34 weeks gestation. [pmid: 11192532].
IJsselstijn H., Tibboel D. The lungs in congenital diaphragmatic hernia: Do we understand?. Pediatr. Pulmonol. 1998;26(3):204-218. No original data. Article does not address any of the Key Questions. [pmid: 9773916].
Inamura N., Kubota A., Nakajima T., Kayatani F., Okuyama H., Oue T., Kawahara H. A proposal of new therapeutic strategy for antenatally diagnosed congenital diaphragmatic hernia. J. Pediatr. Surg. 2005;40(8):1315-1319. No abstractable data. [pmid: 16080939].
Iocono J. A., Cilley R. E., Mauger D. T., Krummel T. M., Dillon P. W. Postnatal pulmonary hypertension after repair of congenital diaphragmatic hernia: Predicting risk and outcome. J. Pediatr. Surg. 1999;34(2):349-353. Article does not address any of the Key Questions. [pmid: 10052821].
Islam S., Masiakos P., Schnitzer J. J., Doody D. P., Ryan D. P. Diltiazem reduces pulmonary arterial pressures in recurrent pulmonary hypertension associated with pulmonary hypoplasia. J. Pediatr. Surg. 1999;34(5):712-714. Article does not include infants born at less than 34 weeks gestation. [pmid: 10359169].
Izhar FM, Rumilla K, Kim Y-J, Hershenson MB, Schreiber MD. Inhaled nitric oxide prevents the increase in tracheal aspirate IL-8 concentrations in premature newborn infants with respiratory distress syndrome. Pediatric Research. 2001;49(4):402A. No abstractable data. [pmid: 11228267].
Izhar FM, Rumilla KM, Borg MJ, Kim Y-J, Hershenson MB, Schreiber MD. Pulmonary safety of inhaled nitric oxide in premature newborn infants with respiratory distress syndrome. Pediatric Research. 2000;47(4):362A. No abstractable data. [pmid: 10709736].
Janzen P. R., Darowski M. Nitric oxide in a premature infant in the operating room. Anesthesiology. 1995;83(6):1388. Article does not address any of the Key Questions. [pmid: 8533951].
Jerwood D. C., Stokes M. A. Nitric oxide in the management of persistent pulmonary hypertension of the newborn--an unusual cause of failure. Paediatr Anaesth. 1995;5(3):193-195. Article does not include infants born at less than 34 weeks gestation. [pmid: 7489441].
Journois D., Lefebvre D., Deny N., Sidhom N., Djamouri R., Vaccaroni L., Safran D. Treatment of the pulmonary hypertension with inhaled nitric oxide following surgey for congenital heart defects: Traitement De L’hypertension Arterielle Pulmonaire Par LE Monoxide D’azote Inhale Lors de la Correction Chirurgicale de Cardiopathies Congenitales. RBM Rev. Eur. Technol. Biomed. 1993;15(3):167-174. Unobtainable.
Journois D., Pouard P., Mauriat P., Malhere T., Vouhe P., Safran D. Inhaled nitric oxide as a therapy for pulmonary hypertension after operations for congenital heart defects. J Thorac Cardiovasc Surg. 1994;107(4):1129-35. Other reason. [pmid: 8159035].
Kachel W., Varnholt V., Lasch P., Muller W., Lorenz C., Wirth H. High-frequency oscillatory ventilation and nitric oxide: Alternative or complementary to ECMO. INT. J. ARTIF. ORGANS. 1995;18(10):589-597. Article does not include pre-term infants who were treated with inhaled nitric oxide. Other reason. [pmid: 8647589].
Kakuya F., Takase M., Ishii N., Kajino M., Hayashi T., Miyamoto K., Muraki S., Iwamoto J., Okuno A. Inhaled nitric oxide therapy via nasopharyngeal tube in an infant with end-stage pulmonary hypertension. Acta Paediatr Jpn. 1998;40(2):155-8. Article does not include infants born at less than 34 weeks gestation. [pmid: 9581308].
Kamiyama M., Kawahara H., Okuyama H., Oue T., Kuroda S., Kubota A., Okada A. Gastroesophageal reflux after repair of congenital diaphragmatic hernia. J. Pediatr. Surg. 2002;37(12):1681-1684. Article does not address any of the Key Questions. [pmid: 12483629].
Karamanoukian H. L., Glick P. L., Zayek M., Steinhorn R. H., Zwass M. S., Fineman J. R., Morin F. C. 3rd. Inhaled nitric oxide in congenital hypoplasia of the lungs due to diaphragmatic hernia or oligohydramnios. Pediatrics. 1994;94(5):715-8. Article does not include infants born at less than 34 weeks gestation. [pmid: 7936901].
Kauffmann F., Nadif R. Candidate interactions. Eur Respir J. 2007;30(1):3-4. No original data. Article does not include infants born at less than 34 weeks gestation. [pmid: 17601967].
Kavvadia V., Greenough A., Lilley J., Laubscher B., Dimitriou G., Boa F., Poyser K. Plasma arginine levels and the response to inhaled nitric oxide in neonates. Biol. Neonate. 1999;76(6):340-347. Article does not address any of the Key Questions. [pmid: 10567762].
Kawakami H., Ichinose F. Inhaled nitric oxide in pediatric cardiac surgery. Int Anesthesiol Clin. 2004;42(4):93-100. No original data. [pmid: 15577703].
Keller RL, Hawgood S, Neuhaus JM, Farmer DL, Lee H, Albanese CT, Harrison MR, Kitterman JA. Infant pulmonary function in a randomized trial of fetal tracheal occlusion for severe congenital diaphragmatic hernia. Pediatric research. 2004;56(5):818-25. Article does not address any of the Key Questions. [pmid: 15319458].
Kelly L. K., Porta N. F., Goodman D. M., Carroll C. L., Steinhorn R. H. Inhaled prostacyclin for term infants with persistent pulmonary hypertension refractory to inhaled nitric oxide. J Pediatr. 2002;141(6):830-2. Article does not include infants born at less than 34 weeks gestation. [pmid: 12461501].
Khawahur H., Kattan A., Al-Alaiyan S., Saidy K. Congenital diaphragmatic hernia: A local experience. Ann. Saudi Med. 1999;19(6):501-504. Article does not include infants born at less than 34 weeks gestation. Article does not address any of the Key Questions. [pmid: 17277467].
Khemani E., McElhinney D. B., Rhein L., Andrade O., Lacro R. V., Thomas K. C., Mullen M. P. Pulmonary artery hypertension in formerly premature infants with bronchopulmonary dysplasia: clinical features and outcomes in the surfactant era. Pediatrics. 2007;120(6):1260-9. Article does not include pre-term infants who were treated with inhaled nitric oxide. Article does not address any of the Key Questions. [pmid: 18055675].
Kieffer F., Kassis M., Coatantiec Y., Magny J. F., Voyer M. Persistent pulmonary hypertension of the newborn and nitric oxide: From the physiology to the therapy: Hypertension arterielle pulmonaire persistante du nouvea-ne et monoxyde d'azote: De la physiologie a la therapeutique. J. Pediatr. Pueric. 1997;10(4):195-199. Unobtainable.
Kiefer A. S., Wickremasinghe A. C., Johnson J. N., Hartman T. K., Hintz S. R., Carey W. A., Colby C. E. Medical management of extremely low-birth-weight infants in the first week of life: a survey of practices in the United States. Am J Perinatol. 2009;26(6):407-18. Article does not address any of the Key Questions. [pmid: 19301226].
Kilbride H. W., Thibeault D. W. Strategies of cardiovascular and ventilatory management in preterm infants with prolonged rupture of fetal membranes and oligohydramnios. J Perinatol. 2002;22(6):510. No original data. [pmid: 12168134].
Kim do H., Park J. D., Kim H. S., Shim S. Y., Kim E. K., Kim B. I., Choi J. H., Park G. W. Survival rate changes in neonates with congenital diaphragmatic hernia and its contributing factors. J Korean Med Sci. 2007;22(4):687-92. Article does not address any of the Key Questions. Article does not include pre-term infants who were treated with inhaled nitric oxide. [pmid: 17728511].
Kinsella JP, Abman SH. High-frequency oscillatory ventilation augments the response to inhaled nitric oxide in persistent pulmonary hypertension of the newborn: Nitric Oxide Study Group. Chest. 1998;114(1 Suppl):100S. Article does not include infants born at less than 34 weeks gestation. Other reason. [pmid: 9676652].
Kinsella J. P., Abman S. H. Clinical approach to inhaled nitric oxide therapy in the newborn with hypoxemia. J. Pediatr. 2000;136(6):717-726. No original data. [pmid: 10839866].
Kinsella J. P., Abman S. H. Efficacy of inhalational nitric oxide therapy in the clinical management of persistent pulmonary hypertension of the newborn. Chest. 1994;105(3 Suppl):92S-94S. Article does not include infants born at less than 34 weeks gestation. [pmid: 8131627].
Kinsella J. P., Abman S. H. Methaemoglobin during nitric oxide therapy with high-frequency ventilation [4]. Lancet 93. 342(8871):615. Article does not address any of the Key Questions. Other reason.
Kinsella J. P., Griebel J., Schmidt J. M., Abman S. H. Use of inhaled nitric oxide during interhospital transport of newborns with hypoxemic respiratory failure. Pediatrics. 2002;109(1):158-161. Article does not address any of the Key Questions. [pmid: 11773560].
Kinsella J. P., Neish S. R., Shaffer E., Abman S. H. Low-dose inhalation nitric oxide in persistent pulmonary hypertension of the newborn. Lancet. 1992;340(8823):819-20. Article does not include infants born at less than 34 weeks gestation. [pmid: 1357246].
Kinsella J. P., Parker T. A., Ivy D. D., Abman S. H. Noninvasive delivery of inhaled nitric oxide therapy for late pulmonary hypertension in newborn infants with congenital diaphragmatic hernia. J. Pediatr. 2003;142(4):397-401. Article does not include infants born at less than 34 weeks gestation. [pmid: 12712057].
Kinsella J. P., Schmidt J. M., Griebel J., Abman S. H. Inhaled nitric oxide treatment for stabilization and emergency medical transport of critically ill newborns and infants. Pediatrics. 1995;95(5):773-6. Article does not include infants born at less than 34 weeks gestation. [pmid: 7724323].
Kinsella J. P., Torielli F., Ziegler J. W., Dunbar Ivy D., Abman S. H. Dipyridamole augmentation of response to nitric oxide [28]. LANCET. 1995;346(8975):647-648. No original data. Article does not address any of the Key Questions. [pmid: 7651043].
Kinsella J. P., Truog W. E., Walsh W. F., Goldberg R. N., Bancalari E., Mayock D. E., Redding G. J., deLemos R. A., Sardesai S., McCurnin D. C., Moreland S. G., Cutter G. R., Abman S. H. Randomized, multicenter trial of inhaled nitric oxide and high-frequency oscillatory ventilation in severe, persistent pulmonary hypertension of the newborn. J Pediatr. 1997;131(1 Pt 1):55-62. Article does not include infants born at less than 34 weeks gestation. [pmid: 9255192].
Kinsella J. P. Clinical trials of inhaled nitric oxide therapy in the newborn. Pediatr Rev. 1999;20(11):e110-3. No original data. [pmid: 10551897].
Kissoon N. Nitric oxide: to inhale or not to inhale. Pediatr Crit Care Med. 2004;5(2):196-198. No original data. [pmid: 15080110].
Knopf D. Neonatology: Help for preterm infants: Neonatologie: Hilfe fur fruhgeborene. Pharm. Ztg. 2005;150(33):29. Not written in English and cannot determine eligibility.
Koh T. H., Gandini D., Vijayakumar P. The neonatal inhaled nitric oxide study. J Pediatr. 2001;138(2):300. No human data included. Other reason. [pmid: 11174648].
Kohelet D. Nitric oxide inhalation and high frequency oscillatory ventilation for hypoxemic respiratory failure in infants. Isr. Med. Assoc. J. 2003;5(1):19-23. Article address Key Question 1 or 2 ONLY and is not a randomized controlled trial. [pmid: 12592952].
Konig K., Henschke P. Successful weaning of nitric oxide facilitated by a single dose of sildenafil in a baby with persistent pulmonary hypertension of the newborn. Pediatr Pulmonol. 2009;44(8):837. Article does not include infants born at less than 34 weeks gestation. [pmid: 19598230].
Kruse-Ruijter M. F., Zimmermann L. J. I. Persistent pulmonary hypertension in a neonate caused by blood aspiration following vaginal blood loss. Persisterende pulmonale hypertensie bij een neonaat door bloedaspiratie ten gevolge van vaginaal bloedverlies. Ned. Tijdschr. Geneeskd. 2007;151(28):1585-1588. Not written in English and cannot determine eligibility. [pmid: 17715769].
Kulkarni A. Changing trends in neonatal pharmacotherapy. Perinatology. 2004;6(5):231-236. No original data.
Lago P., Meneghini L., Chiandetti L., Tormena F., Metrangolo S., Gamba P. Congenital diaphragmatic hernia: Intensive care unit or operating room?. Am. J. Perinatol. 2005;22(4):189-197. Article does not include infants born at less than 34 weeks gestation. Article does not address any of the Key Questions. [pmid: 15906212].
Lakatos L., Oroszlan G. Possible effect of D-penicillamine on the physiologic action of inhaled nitric oxide in neonates. J Pediatr. 1994;124(4):656-7. No original data. No human data included. [pmid: 8151489].
Lakatos L. [Effect of penicillamine D, nitric oxide, or both?]. Orv Hetil. 1993;134(41):2283. Not written in English and cannot determine eligibility. Article does not include pre-term infants who were treated with inhaled nitric oxide. [pmid: 8414471].
Laubscher B., Greenough A., Kavvadia V., Devane S. P. Response to nitric oxide in term and proterm infants. EUR. J. PEDIATR. 1997;156(8):639-642. Article does not address any of the Key Questions. No abstractable data. [pmid: 9266198].
Lal M. K., Field D. J. Clinical management of persistent pulmonary hypertension of the newborn. Perinatology. 2001;3(5):249-261. Unobtainable.
Lee S. K., McMillan D. D., Ohlsson A., Pendray M., Synnes A., Whyte R., Chien L. Y., Sale J. Variations in practice and outcomes in the Canadian NICU network: 1996-1997. Pediatrics. 2000;106(5):1070-9. Article does not address any of the Key Questions. [pmid: 11061777].
Leipala J. A., Williams O., Sreekumar S., Cheeseman P., Rafferty G. F., Hannam S., Milner A., Greenough A. Exhaled nitric oxide levels in infants with chronic lung disease. Eur. J. Pediatr. 2004;163(9):555-558. Article does not address any of the Key Questions. [pmid: 15205950].
Lemke R. P., Belik J., Giddins N. G., Fajardo C. A., Manitoba. Clinical experience in the use of inhaled nitric oxide in infants with pulmonary hypertension. Experience clinique relative a l'utilisation d'oxyde nitrique en inhalation chez les nourrissons atteints d'hypertension pulmonaire. Can. Respir. J. 1996;3(5):295-300. No abstractable data.
Li J. H. [Treatment of periventricular leukomalacia in preterm infants]. Zhongguo Dang Dai Er Ke Za Zhi. 2007;9(4):327-9. Not written in English and cannot determine eligibility. [pmid: 17706032].
Lindner W., Pohlandt F., Grab D., Flock F. Acute respiratory failure and short-term outcome after premature rupture of the membranes and oligohydramnios before 20 weeks of gestation. J. Pediatr. 2002;140(2):177-182. Article does not address any of the Key Questions. [pmid: 11865268].
Lindroth M. [Are there any cost-benefit limits in connection with neonatal care?]. Lakartidningen. 2002;99(3):208. Not written in English and cannot determine eligibility. [pmid: 11838082].
Lonnqvist P. A., Jonsson B. [Premature infants benefit from inhaled nitric oxide, too. Not only full-term infants with severe hypoxic respiratory failure]. Lakartidningen. 2005;102(50):3880-2. Not written in English and cannot determine eligibility. Article does not include infants born at less than 34 weeks gestation. [pmid: 16425863].
Lonnqvist P. A., Jonsson B., Winberg P., Frostell C. G. Inhaled nitric oxide in infants with developing or established chronic lung disease. Acta Paediatr. 1995;84(10):1188-92. No abstractable data. [pmid: 8563234].
Lonnqvist P. A. Efficacy and economy of inhaled nitric oxide in neonates accepted for extra-corporeal membrane oxygenation. Acta Physiol Scand. 1999;167(2):175-9. Article does not include infants born at less than 34 weeks gestation. Article does not address any of the Key Questions. [pmid: 10571554].
Lonnqvist P. A. Inhaled nitric oxide in newborn and paediatric patients with pulmonary hypertension and moderate to severe impaired oxygenation: Effects of doses of 3-100 parts per million. Intensive Care Med. 1997;23(7):773-779. Article does not include infants born at less than 34 weeks gestation. [pmid: 9290992].
Lopez Herrera M. C., Roman L., Lopez De Heredia J., Valls Soler I. A. Nitric oxide administration [1]: Administracion de Oxido Nitrico [1]. An. Esp. Pediatr. 1995;43(4):293-294. Not written in English and cannot determine eligibility. Other reason.
Lopez-Herce Cid J., Garcia Sanchez E., Garcia Sanz C., Ruperez Lucas M., Alcaraz Romero A., Carrillo Alvarez A. [Effects of prone position, inhaled nitric oxide and surfactant in children with hypoxemic pulmonary disease]. An Pediatr (Barc). 2003;58(2):106-14. Not written in English and cannot determine eligibility. [pmid: 12628140].
Lopez-Herce Cid J., Sanchez Galindo A., Carrillo Alvarez A., Sancho Perez L., Serina Ramirez C., Cuesta Alvaro P. [Nitric oxide treatment in children: clinical course, toxicity and factors influencing its effects]. An Esp Pediatr. 1997;46(6):542-8. Not written in English and cannot determine eligibility. [pmid: 9297420].
Lopez-Herce Cid J., Sanchez Galindo A., Carrillo Alvarez A., Sancho Perez L., Serina Ramirez C., Cuesta Alvaro P. Nitric oxide treatment in children: Clinical evolution, toxicity and factors influencing its effects. Tratamiento con oxido nitrico en ninos: Evolucion clinica, toxicidad y factores que influyen en la respuesta. An. Esp. Pediatr. 1997;46(6):542-548. Not written in English and cannot determine eligibility. [pmid: 9297420].
Lopez-Herce Cid J., Cueto Calvo E., Carrillo Alvarez A., Vazquez Garcia P., Bustinza Arriortua A., Moral Torrero R. Acute effects of inhaled nitric oxide in children: Respuesta aguda a la administracion de oxido nitrico en ninos. An. Esp. Pediatr. 1997;46(6):581-586. Unobtainable. [pmid: 9297427].
Lorch S A, Cnaan A, Barnhart K. Cost-effectiveness of inhaled nitric oxide for the management of persistent pulmonary hypertension of the newborn (Structured abstract). Pediatrics. 2004;114(2):417-426. Article does not include infants born at less than 34 weeks gestation. Article does not address any of the Key Questions. [pmid: 15286225].
Lorch S. A., Banks B. A., Christie J., Merrill J. D., Althaus J., Schmidt K., Ballard P. L., Ischiropoulos H., Ballard R. A. Plasma 3-nitrotyrosine and outcome in neonates with severe bronchopulmonary dysplasia after inhaled nitric oxide. Free Radic Biol Med. 2003;34(9):1146-52. No abstractable data. [pmid: 12706495].
Lu Y., Sun B. [Effect of inhaled nitric oxide on methemoglobin levels in children]. Zhongguo Dang Dai Er Ke Za Zhi. 2008;10(2):257-8. Not written in English and cannot determine eligibility. [pmid: 18433566].
Luis A. L., Avila L. F., Encinas J. L., Andres A. M., Suarez O., Elorza D., Rodriguez I., Martinez L., Murcia J., Lassaletta L., Tovar J. A. Results of the treatment of congenital diaphagmatic hernia with conventional terapeutics modalities: Resultados en el tratamiento de la hernia diafragmaitica con terapias convencionales. Cir Pediatr. 2006;19(3):167-172. Not written in English and cannot determine eligibility. [pmid: 17240950].
Maderuelo Rodriguez E., Sanz Lopez E., Franco Fernandez M. L., Bernardo Atienza B., Sanchez Luna M. Rescue treatment with inhaled nitric oxide in preterm newborns with respiratory failure: Oxido nitrico inhalado como rescate en insuficiencia respiratoria del recien nacido inmaduro. An. Pediatr. 2005;62(1):68-71. Not written in English and cannot determine eligibility.
Martin R. J. Nitric oxide for preemies--not so fast. N Engl J Med. 2003;349(22):2157-9. No original data. [pmid: 14645644].
Meadow W., Lee G., Lin K., Lantos J. Changes in mortality for extremely low birth weight infants in the 1990s: implications for treatment decisions and resource use. Pediatrics. 2004;113(5):1223-9. Article does not include pre-term infants who were treated with inhaled nitric oxide. Article does not address any of the Key Questions. [pmid: 15121933].
Mercier J. C., Zupan V., Renaudin M. H., Raveau C., Dehan M. Inhaled nitric oxide in newborns: Inhalation de Monoxide d'Azote: Espoirs et Precautions en Neonatologie. RBM Rev. Eur. Technol. Biomed. 1993;15(3):150-155. Not written in English and cannot determine eligibility.
Mercier J. C. Uncertainties about the use of inhaled nitric oxide in preterm infants. Acta Paediatr Suppl. 2001;90(436):15-8. No original data. [pmid: 11332949].
Mercier J.-C., Lacaze T., Storme L., Roze J.-C., Dinh-Xuan A. T., Dehan M., Zupan V., Gouyon J. B., Francoise M., Durand P., Galperine I., Oriot D., Menget A., Daoud P., Jouvet P., Morville P., Devaux A. M., Desfreres L., Magny J. F., Simeoni U. Disease-related response to inhaled nitric oxide in newborns with severe hypoxaemic respiratory failure. Eur. J. Pediatr. 1998;157(9):747-752. No abstractable data. [pmid: 9776535].
Mercier J.-C., Zupan V., Dehan M., Renaudin M.-H., Bouchet M., Raveau C. Device to monitor concentration of inhaled nitric oxide [5]. Lancet. 1993;342(8868):431-432. No original data. Article does not address any of the Key Questions. [pmid: 8101923].
Mersal A., Attili I., Alkhotani A. Severe neonatal pulmonary hypertension secondary to antenatal maternal diclofenac ingestion reversed by inhaled nitric oxide and oral sildenafil. Ann Saudi Med. 2007;27(6):448-9. Article does not include infants born at less than 34 weeks gestation. [pmid: 18059116].
Migliazza L., Bellan C., Alberti D., Auriemma A., Burgio G., Colombo G. L. e. A. Retrospective study of 111 cases of congenital diaphragmatic hernia treated with early high-frequency oscillatory ventilation and presurgical stabilization. J. Pediatr. Surg. 2007;42(9):1526-1532. Article does not include infants born at less than 34 weeks gestation. Article does not address any of the Key Questions. [pmid: 17848243].
Miller A. A. Diseases of progress in neonatal care [1]. J. Perinatol. 2005;25(8):557. No original data. [pmid: 16047035].
Milner A. D., Aiton N. Nitric oxide inhalation. Pediatr Pulmonol Suppl. 1995;11:100-101. No original data. [pmid: 7547315].
Moore F. A., Haenel J. B. Ventilatory strategies for acute respiratory failure. Am J Surg. 1997;173(1):53-6. discussion 57-8. No original data. Article does not address any of the Key Questions.
Morin F. C. 3rd, Stenmark K. R. Persistent pulmonary hypertension of the newborn. Am J Respir Crit Care Med. 1995;151(6):2010-32. No original data. [pmid: 7767553].
Mosca F., Bray M., Stucchi I., Fumagalli M. Pulmonary hypertension after ibuprofen prophylaxis in very preterm infants [5]. Lancet. 2002;360(9338):1023-1024. Article does not address any of the Key Questions. [pmid: 12383692].
Motti A., Tissot C., Rimensberger P. C., Prina-Rousso A., Aggoun Y., Berner M., Beghetti M., Da Cruz E. Intravenous adenosine for refractory pulmonary hypertension in a low-weight premature newborn: A potential new drug for rescue therapy. Pediatr. Crit. Care Med. 2006;7(4):380-382. Article does not address any of the Key Questions. [pmid: 16738499].
Mourani P. M., Ivy D. D., Gao D., Abman S. H. Pulmonary vascular effects of inhaled nitric oxide and oxygen tension in bronchopulmonary dysplasia. Am J Respir Crit Care Med. 2004;170(9):1006-13. Article does not include infants born at less than 34 weeks gestation. Article does not include pre-term infants who were treated with inhaled nitric oxide. [pmid: 15184202].
Movahhedian H. R., Kashani I. A., Sine D., Bull D., Lyons Jones K., Rothman A. Pulmonary hypertension and trisomy 16. Pediatr. Cardiol. 1998;19(2):187-189. Article does not include infants born at less than 34 weeks gestation. [pmid: 9565517].
Muller W., Kachel W., Kuntz S., Lasch P., Varnholt V. Treatment of severe persistent pulmonary hypertension of the newborn (PPHN) with nitric oxide (NO). DIE BEHANDLUNG DER PERSISTIERENDEN PULMONALEN HYPERTONIE DES NEUGEBORENEN (PPHN) DURCH STICKOXIDINHALATION (NO). MONATSSCHR. KINDERHEILKD. 1995;143(5):466-474. Not written in English and cannot determine eligibility.
Munshi U. K., Clark D. A. Meconium aspiration syndrome. Contemp. Clin. Gynecol. Obstet. 2002;2(3):247-254. No original data.
Mupanemunda R. H., Edwards A. D. Treatment of newborn infants with inhaled nitric oxide. Arch Dis Child Fetal Neonatal Ed. 1995;72(2):F131-4. No original data. [pmid: 7712274].
Nakajima W., Ishida A., Arai H., Takada G. Methaemoglobinaemia after inhalation of nitric oxide in infant with pulmonary hypertension. Lancet. 9197;350(9083):1002-3. Article does not include infants born at less than 34 weeks gestation. [pmid: 9329519].
Namachivayam P, Theilen U, Butt WW, Cooper SM, Penny DJ, Shekerdemian LS. Sildenafil prevents rebound pulmonary hypertension after withdrawal of nitric oxide in children. American journal of respiratory and critical care medicine. 2006;174(9):1042-7. Article does not address any of the Key Questions. Other reason. [pmid: 16917115].
Nawaz A., Shawis R., Matta H., Jacobsz A., Al-Salem A. Congenital diaphragmatic hernia: The impact of preoperative stabilization on outcome. Ann. Saudi Med. 1999;19(6):541-543. Article does not include infants born at less than 34 weeks gestation. Article does not include pre-term infants who were treated with inhaled nitric oxide. [pmid: 17277478].
Ng G. Y., Derry C., Marston L., Choudhury M., Holmes K., Calvert S. A. Reduction in ventilator-induced lung injury improves outcome in congenital diaphragmatic hernia?. Pediatr Surg Int. 2008;24(2):145-50. Article does not address any of the Key Questions. [pmid: 17973115].
Ng P. C., Fok T. F., Lee C. H., Cheung K. L., So K. W., To K. F., Wong W. Congenital cytomegalovirus infection presenting as severe persistent pulmonary hypertension of the newborn. J Perinatol. 1998;18(3):234-237. Article does not include infants born at less than 34 weeks gestation. [pmid: 9659657].
Ngougmna E., Ostrea E. M. Jr., Konduri G. G. Analysis of nonsteroidal antiinflammatory drugs in meconium and its relation to persistent pulmonary hypertension of the newborn. Pediatrics. 2001;107(3):519-523. Article does not include infants born at less than 34 weeks gestation. [pmid: 11230592].
Nicholl R. Nitric oxide in preterm babies. Arch Dis Child. 2002;86(1):59-60. No original data. [pmid: 11806888].
Noori S., Friedlich P., Wong P., Garingo A., Seri I. Cardiovascular effects of sildenafil in neonates and infants with congenital diaphragmatic hernia and pulmonary hypertension. Neonatology. 2007;91(2):92-100. No abstractable data. [pmid: 17344658].
Norden M. A., Butt W., McDougall P. Predictors of survival for infants with congenital diaphragmatic hernia. J Pediatr Surg. 1994;29(11):1442-6. Article does not include infants born at less than 34 weeks gestation. Other reason. [pmid: 7844717].
Normand C. E., Field D., Elbourne D., Truesdale A. Nitric oxide is not licensed for preterm neonates. BMJ. 2002;325(7374):1244. No original data. [pmid: 12446552].
Obara H., MIkawa K., Nishina K., Maekawa N., Kawai S., Hisano K., Shiga M., Suzuki K., Iga K., Ri Y. Inhalational nitric oxide therapy for pulmonary hypertension. Masui. 1994;43(Suppl):S207-215. Not written in English and cannot determine eligibility. [pmid: 7853657].
Ochikubo C. G., Waffarn F., Turbow R., Kanakriyeh M. Echocardiographic evidence of improved hemodynamics during inhaled nitric oxide therapy for persistent pulmonary hypertension of the newborn. Pediatr Cardiol. 1997;18(4):282-7. Article does not include infants born at less than 34 weeks gestation. Article does not address any of the Key Questions. [pmid: 9175525].
Okawada M., Okazaki T., Yamataka A., Yanai T., Kato Y., Kobayashi H., Lane G. J., Miyano T. Efficacy of protocolized management for congenital diaphragmatic hernia. a review of 100 cases. Pediatr Surg Int. 2006;22(11):925-30. Article does not include infants born at less than 34 weeks gestation. [pmid: 16969680].
Okazaki T., Okawada M., Shiyanagi S., Shoji H., Shimizu T., Tanaka T., Takeda S., Kawashima K., Lane G. J., Yamataka A. Significance of pulmonary artery size and blood flow as a predictor of outcome in congenital diaphragmatic hernia. Pediatr Surg Int. 2008;24(12):1369-73. Article does not include infants born at less than 34 weeks gestation. [pmid: 18985361].
Okuyama H., Kubota A., Kawahara H., Oue T., Kitayama Y., Yagi M. Correlation between lung scintigraphy and long-term outcome in survivors of congenital diaphragmatic hernia. Pediatr. Pulmonol. 2006;41(9):882-886. Article does not include infants born at less than 34 weeks gestation. Article does not address any of the Key Questions. [pmid: 16850440].
Okuyama H., Kubota A., Oue T., Kuroda S., Ikegami R., Kamiyama M., Kitayama Y., Yagi M. Inhaled nitric oxide with early surgery improves the outcome of antenatally diagnosed congenital diaphragmatic hernia. J Pediatr Surg. 2002;37(8):1188-90. Article does not include infants born at less than 34 weeks gestation. [pmid: 12149699].
Oriot D., Boussemart T., Berthier M., Bonneau D., Coisne D. Paradoxical effect of inhaled nitric oxide in a newborn with pulmonary hypertension. Lancet. 1993;342(8867):364-5. Article does not include infants born at less than 34 weeks gestation. [pmid: 8101598].
Osiovich H. C. Improving survival of neonates with isolated congenital diaphragmatic hernia. Indian Pediatr. 2004;41(11):1138-42. Article does not include infants born at less than 34 weeks gestation. [pmid: 15591664].
Parker T. A., Ivy D. D., Kinsella J. P., Torielli F., Ruyle S. Z., Thilo E. H., Abman S. H. Combined therapy with inhaled nitric oxide and intravenous prostacyclin in an infant with alveolar-capillary dysplasia. Am. J. Respir. Crit. Care Med. 1997;155(2):743-746. Article does not include infants born at less than 34 weeks gestation. [pmid: 9032222].
Parker T. A., Kinsella J. P., Abman S. H. Response to inhaled nitric oxide in persistent pulmonary hypertension of the newborn: relationship to baseline oxygenation. J Perinatol. 1998;18(3):221-5. Article does not include infants born at less than 34 weeks gestation. [pmid: 9659654].
Patole S., Lee J., Whitehall J. Adenosine infusion in the management of a micropremi neonate with pulmonary hypertension. Indian Pediatr. 1999;36(3):307-310. Article does not include pre-term infants who were treated with inhaled nitric oxide. Article does not address any of the Key Questions. [pmid: 10713845].
Pawlik T. D., Porta N. F., Steinhorn R. H., Ogata E., deRegnier R. A. Medical and financial impact of a neonatal extracorporeal membrane oxygenation referral center in the nitric oxide era. Pediatrics. 2009;123(1):e17-24. Article does not include infants born at less than 34 weeks gestation. Article does not address any of the Key Questions. [pmid: 19064612].
Peliowski A., Finer N. N., Etches P. C., Tierney A. J., Ryan C. A. Inhaled nitric oxide for premature infants after prolonged rupture of the membranes. J Pediatr. 1995;126(3):450-3. Article does not address any of the Key Questions. [pmid: 7869210].
Perreault T. ECMO or no ECMO: Do no harm: ECMO o no ECMO: No hacer dano. An. Esp. Pediatr. 2002;57(1):1-4. Unobtainable. [pmid: 12139885].
Peterson A. L., Deatsman S., Frommelt M. A., Mussatto K., Frommelt P. C. Correlation of echocardiographic markers and therapy in persistent pulmonary hypertension of the newborn. Pediatr Cardiol. 2009;30(2):160-5. Article does not include infants born at less than 34 weeks gestation. Article does not address any of the Key Questions. [pmid: 18779989].
Petros A. J., Cox P. B., Bohn D. Simple method for monitoring concentration of inhaled nitric oxide [21]. Lancet. 1992;340(8828):1167. Article does not address any of the Key Questions. Other reason. [pmid: 1359248].
Pierce C. M., Petros A. J., Fielder A. R. No evidence for severe retinopathy of prematurity following sildenafil [14]. Br. J. Ophthalmol. 2005;89(2):250. No original data. [pmid: 15665374].
Posencheg M. A., Gow A. J., Truog W. E., Ballard R. A., Cnaan A., Golombek S. G., Ballard P. L. Inhaled nitric oxide in premature infants: effect on tracheal aspirate and plasma nitric oxide metabolites. J Perinatol. 2009. No abstractable data.
Puckett B. Congenital diaphragmatic hernia: two case studies with atypical presentations. Neonatal Netw. 2006;25(4):239-49. Article does not include infants born at less than 34 weeks gestation. [pmid: 16913235].
Raimondi F., Migliaro F., Capasso L., Ausanio G., Bisceglia M., Giliberti P., Messina F., Salvia G., Paludetto R. Intravenous magnesium sulphate vs. inhaled nitric oxide for moderate, persistent pulmonary hypertension of the newborn. A Multicentre, retrospective study. J Trop Pediatr. 2008;54(3):196-9. Article does not include infants born at less than 34 weeks gestation. [pmid: 18048460].
Reliability and Accuracy of Cranial Ultrasound in the NICHD Randomized Controlled Trial of Inhaled Nitric Oxide for Premature Infants with Severe Respiratory Failure, American Pediatric Society/SocieTY for Pediatric Research Abstract. 2006. CODEN. RCT. ISSN: CN-00711876. Unobtainable.
Rennie J. M., Bokhari S. A. Recent advances in neonatology. Arch Dis Child Fetal Neonatal Ed. 1999;81(1):F1-4. No original data. [pmid: 10375353].
Reyes C., Chang L. K., Waffarn F., Mir H., Warden M. J., Sills J. Delayed repair of congenital diaphragmatic hernia with early high-frequency oscillatory ventilation during preoperative stabilization. J Pediatr Surg. 1998;33(7):1010-4. discussion 1014-6. Article does not include pre-term infants who were treated with inhaled nitric oxide.
Riddle E. M., Feltes T. F., Rosen K., Fraley J. K., Mott A. R., Kovalchin J. P. Association of nitric oxide dose and methemoglobin levels in patients with congenital heart disease and pulmonary hypertension. Am J Cardiol. 2002;90(4):442-4. Article does not include infants born at less than 34 weeks gestation. Other reason. [pmid: 12161242].
Rieger-Fackeldey E., Genzel-Boroviczeny O., Schulze A. Severe systemic cytomegalovirus infection of premature infants acquired through breastmilk: Schwere systemische zytomegalie-virusinfektion fruhgeborener uber die muttermilch. Monatsschr. Kinderheilkd. 2001;149(10):1059-1062. Not written in English and cannot determine eligibility.
Rite Gracia S., Ruiz Moreno J. A., Sanchez Gimeno J., Molina Chica M. I., Marco Tello A., Rite Montanes S. [Inhaled nitric oxide in the treatment of persistent pulmonary hypertension in a newborn]. An Esp Pediatr. 1999;51(2):181-5. Not written in English and cannot determine eligibility. [pmid: 10495506].
Roberts J. D. Jr. Inhaled nitric oxide for treatment of pulmonary artery hypertension in the newborn and infant. Crit Care Med. 1993;21(9 Suppl):S374-6. No original data. [pmid: 8365236].
Roberts J. D., Polaner D. M., Lang P., Zapol W. M. Inhaled nitric oxide in persistent pulmonary hypertension of the newborn. Lancet. 1992;340(8823):818-819. Article does not include infants born at less than 34 weeks gestation. [pmid: 1357245].
Roberta AB. Improved Outcome with Inhaled Nitric Oxide in Preterm Infants Mechanically Ventilated at 7&ndash;21 Days of Age, American Pediatric Society/SocieTY for Pediatric Research Abstract. 2006. Coden. RCT. ISSN: CN-00711486. Unobtainable.
Robinson T., Stewart D. L., Hilbert T. Use of inhaled nitric oxide for the treatment of persistent pulmonary hypertension of the newborn (PPHN). J Ky Med Assoc. 1999;97(3):100-4. No original data. Article does not include infants born at less than 34 weeks gestation. [pmid: 10189770].
Rocha G. M., Bianchi R. F., Severo M., Rodrigues M. M., Baptista M. J., Correia-Pinto J., Guimaraes H. A. Congenital diaphragmatic hernia - The neonatal period (Part I). Eur. J. Pediatr. Surg. 2008;18(4):219-223. Article does not include infants born at less than 34 weeks gestation. Article does not address any of the Key Questions. [pmid: 18704887].
Roofthooft M. T. R., Bergman K. A., Waterbolk T. W., Ebels T., Bartelds B., Berger R. M. F. Persistent Pulmonary Hypertension of the Newborn With Transposition of the Great Arteries. Ann. Thorac. Surg. 2007;83(4):1446-1450. No abstractable data. Article does not include pre-term infants who were treated with inhaled nitric oxide. [pmid: 17383355].
Rosati E., Butera G., Bossone E., De Felice C., Latini G. Inhaled nitric oxide and oral nifedipine in a preterm infant with bronchopulmonary dysplasia and pulmonary hypertension. Eur. J. Pediatr. 2007;166(7):737-738. No abstractable data. [pmid: 17103192].
Rosenberg A. A. Inhaled nitric oxide in the premature infant with severe hypoxemic respiratory failure: A time for caution. J. Pediatr. 1998;133(6):720-722. No original data. [pmid: 9842030].
Roze J.-C., Storme L., Zupan V., Morville P., Dinh-Xuan A. T., Mercier J.-C. Echocardiographic investigation of inhaled nitric oxide in newborn babies with severe hypoxaemia. Lancet. 1994;344(8918):303-305. No abstractable data. [pmid: 7914264].
Rutter N. Persistent pulmonary hypertension of the newborn. Care Crit. Ill. 1993;9(5):206-208. No original data.
Ryan A., Tobias J. D. A 5-year survey of nitric oxide use in a pediatric intensive care unit. Am J Ther. 2007;14(3):253-8. Article does not address any of the Key Questions. [pmid: 17515699].
Sarici S. U., Kul M., Candemir G., Gursel O., Alpay F., Gokcay E. Inhaled nitric oxide in a preterm newborn with severe hypoxemic respiratory failure. Gulhane Med. J. 2004;46(3):255-257. Article does not address any of the Key Questions.
Saugstad O. D. Inhaled nitric oxide for preterm infants - Still an experimental therapy. Lancet. 1999;354(9184):1047-1048. No original data. [pmid: 10509489].
Saura L., Castanon M., Prat J., Albert A., Caceres F., Moreno J., Gratacos E. Impact of fetal intervention on postnatal management of congenital diaphragmatic hernia. Eur J Pediatr Surg. 2007;17(6):404-7. Article does not address any of the Key Questions. Other reason. [pmid: 18072025].
Saw H.-P., Ho M.-L., Chen J.-Y. Hearing impairment in very low birth weight infants incidence, risks factors analysis and follow up. Clin. Neonatol. 2005;12(1):30-35. Article does not address any of the Key Questions. Other reason.
Saxena A. K., Haxihja E., Kleinlein B., Hollwarth M. E. Lymphoceles in premature infants after congenital diaphragmatic hernia repair: Thoracoscopic management. J. Thorac. Cardiovasc. Surg. 2007;133(2):584-585. Article does not address any of the Key Questions. [pmid: 17258613].
Saygili A., Ledieu C., Casterman P., Leke A., Maingourd Y., Krim G. [Value of nitric oxide (NO) in neonatal right ventricular dysfunction]. Arch Pediatr. 1998;5(1):93-4. Not written in English and cannot determine eligibility. [pmid: 10223123].
Schmolzer G., Urlesberger B., Reiterer F., Haim M., Kutschera J., Resch B., Muller W. Inhaled Nitric Oxide by Pulmonary Hypertension: Comparison Preterm Infants versus Newborn Infants: Inhalative Therapie mit Stickstoffmonoxid bei pulmonaler Hypertension: Vergleich des Effektes bei Fruh- und Neugeborenen. Klin. Padiatr. 2003;215(5):257-261. Not written in English and cannot determine eligibility. [pmid: 14520586].
Schnapf B. M., Barness E. G., Ackerman J., Pomerance H. H. A newborn infant with tachypnea, intercostal retractions, and poor oxygen saturation. Pediatr. Pathol. Mol. Med. 2000;19(1):73-84. Article does not include infants born at less than 34 weeks gestation.
Schreiber M. D., Marks J. D. No definitive recommendation for iNO in preterm infants. J Pediatr. 2006;149(1):146-7. author reply 147. No abstractable data. [pmid: 16860152].
Schreiber M. D., Gin-Mestan K., Marks J. D., Huo D., Lee G., Srisuparp P., Meau-Petit V. Inhaled nitric oxide in premature infants with the respiratory distress syndrome. Commentary. Arch. Pediatr. 2004;11(11):1367-1368. No original data.
Schreiber M. D. Methylene blue: NO panacea. J Pediatr. 1996;129(6):790-3. No original data. [pmid: 8969718].
Sebald M., Friedlich P., Burns C., Stein J., Noori S., Ramanathan R., Seri I. Risk of need for extracorporeal membrane oxygenation support in neonates with congenital diaphragmatic hernia treated with inhaled nitric oxide. J. Perinatol. 2004;24(3):143-146. Article does not address any of the Key Questions. [pmid: 14961042].
Seeniraj K. Respiratory distress in new born: Surgical causes and management. Ind. J. Pract. Pediatr. 2004;6(1):27-31. No original data.
Sehgal A., Callander I., Stack J., Momsen T., Sterling-Levis K. Experience with inhaled nitric oxide therapy in hypoxic respiratory failure of the newborn. Indian J Chest Dis Allied Sci. 2005;47(4):245-9. Article does not address any of the Key Questions. [pmid: 16255395].
Sehgal A. Continuous positive airway pressure - A gentler approach to ventilation [3]. Indian Pediatr. 2005;42(4):393-394. No original data. No human data included. [pmid: 15876608].
Shah N., Jacob T., Exler R., Morrow S., Ford H., Albanese C., Wiener E., Rowe M., Billiar T., Simmons R., et al. Inhaled nitric oxide in congenital diaphragmatic hernia. J Pediatr Surg. 1994;29(8):1010-4. discussion 1014-5. Article does not include infants born at less than 34 weeks gestation.
Shiyanagi S., Okazaki T., Shoji H., Shimizu T., Tanaka T., Takeda S., Kawashima K., Lane G. J., Yamataka A. Management of pulmonary hypertension in congenital diaphragmatic hernia: nitric oxide with prostaglandin-E1 versus nitric oxide alone. Pediatr Surg Int. 2008;24(10):1101-4. Article does not include infants born at less than 34 weeks gestation. [pmid: 18726605].
Singh M., Kumar L. Management of respiratory failure. Indian J Pediatr. 1996;63(1):53-60. No original data. [pmid: 10829965].
Siobal M. S. Combining heliox and inhaled nitric oxide as rescue treatment for pulmonary interstitial emphysema. Respir. Care. 2009;54(7):976-977. Article does not address any of the Key Questions. [pmid: 19558748].
Skimming JW, Bender KA, Hutchison AA, Drummond WH. Nitric oxide inhalation in infants with respiratory distress syndrome. The Journal of pediatrics. 1997;130(2):225-30. No abstractable data. [pmid: 9042124].
Skimming JW, Burchfield DJ, Wood CE, Banner MJ. Nitric oxide inhalation facilitates carbon dioxide elimination in preterm infants with respiratory distress syndrome. Pediatric Research. 2001;49(4):283A. Article does not address any of the Key Questions.
Skott O. Renin. Am. J. Physiol. Regul. Integr. Comp. Physiol. 2002;282(4 51-4):R937-R939. No original data.
Smyth R. L. Inhaled nitric oxide treatment for preterm infants with hypoxic respiratory failure. Thorax. 2000;55(Suppl 1):S51-5. No original data. [pmid: 10943640].
Soares S., Rocha G., Pissarra S., Carrico A., Azevedo I., Simoes J. S., Guimaraes H. Pertussis with severe pulmonary hypertension in a newborn with good outcome - Case report: Infeccao por Bordetella pertussis com hipertensao pulmonar grave num recem-nascido com boa evolucao clinica - Caso clinico. Rev. Port. Pneumol. 2008;14(5):687-692. Article does not include infants born at less than 34 weeks gestation. [pmid: 18781268].
Sokol G. M., Fineberg N. S., Wright L. L., Ehrenkranz R. A. Changes in arterial oxygen tension when weaning neonates from inhaled nitric oxide. Pediatr Pulmonol. 2001;32(1):14-9. Article does not include infants born at less than 34 weeks gestation. [pmid: 11416871].
Sood B. G. Re: Neonatal nitric oxide use: predictors of response and financial implications. J Perinatol. 2004;24(2):132. author reply 133. No original data. Article does not address any of the Key Questions. [pmid: 14872214].
Sreenan C., Etches P., Osiovich H. The western Canadian experience with congenital diaphragmatic hernia: Perinatal factors predictive of extracorporeal membrane oxygenation and death. Pediatr. Surg. Int. 2001;17(2-3):196-200. Article does not include infants born at less than 34 weeks gestation. Article does not address any of the Key Questions. [pmid: 11315287].
Steinhorn R. H., Cox P. N., Fineman J. R., Finer N. N., Rosenberg E. M., Silver M. M., Tyebkhan J., Zwass M. S., Morin F. C. 3rd. Inhaled nitric oxide enhances oxygenation but not survival in infants with alveolar capillary dysplasia. J Pediatr. 1997;130(3):417-22. Article does not include infants born at less than 34 weeks gestation. [pmid: 9063417].
Steinhorn R. H. Persistent pulmonary hypertension of the newborn. Acta Anaesthesiol Scand Suppl. 1997;111:135-140. No original data. [pmid: 9420986].
Stoll B. J., Hansen N. Infections in VLBW infants: Studies from the NICHD Neonatal Research Network. Semin. Perinatol. 2003;27(4):293-301. No original data. [pmid: 14510320].
Stranak Z., Janota J., Pycha K., Snajdauf J., Simak J. [Delayed surgery in congenital diaphragmatic hernia without drainage of the ipsilateral hemithorax]. Rozhl Chir. 1999;78(12):622-6. Not written in English and cannot determine eligibility. [pmid: 10746084].
Stranak Z., Zabrodsky V., Simak J. Changes in alveolar-arterial oxygen difference and oxygenation index during low-dose nitric oxide inhalation in 15 newborns with severe respiratory insufficiency. Eur J Pediatr. 1996;155(10):907-10. Article does not address any of the Key Questions. Other reason. [pmid: 8891564].
Stranak Z., Zabrodsky V., Simak J. Inhalation of nitric oxide in critically ill newborns. First clinical experience at the Inst. for the Care of Mother and Child, Prague. Inhalace Oxidu Dusnateho U Kriticky Nemocnych Novorozenco. Prvniklinicke Zkusenostiv Upmd Praha. Cesko-Slov. Pediatr. 1995;50(5):275-279. Not written in English and cannot determine eligibility.
Subhedar NV, Shaw NJ. Neurodevelopmental outcome with inhaled nitric oxide therapy. The Journal of pediatrics. 1999;135(2 Pt 1):266-7. No abstractable data. [pmid: 10431128].
Subhedar N., Dewhurst C. Is nitric oxide effective in preterm infants?. Arch Dis Child Fetal Neonatal Ed. 2007;92(5):F337-41. No original data. [pmid: 17712184].
Subhedar N. V., Shaw N. J. Changes in oxygenation and pulmonary haemodynamics in preterm infants treated with inhaled nitric oxide. Arch Dis Child Fetal Neonatal Ed. 1997;77(3):F191-7. No abstractable data. [pmid: 9462188].
Subhedar N. V., Shaw N. J. Inhaled nitric oxide in preterm infants at high risk of developing chronic lung disease (CLD). Early Hum. Dev. 1997;49(3):211-212. Article does not address any of the Key Questions.
Subhedar N. V., Jauhari P., Natarajan R. Cost of inhaled nitric oxide therapy in neonates [8]. Lancet. 2002;359(9319):1781-1782. No original data. Article does not address any of the Key Questions. [pmid: 12049900].
Sun B. Current progress of clinical trials for new drug evaluation in neonatal and pediatric clinics in China. Zhongguo Yao Li Xue Bao. 1997;18(6):537-9. No original data. [pmid: 10322915].
Susan RH. Neurodevelopmental Outcomes of the NICHD Randomized Controlled Trial of iNO for Premature Infants with Severe Respiratory Failure, American Pediatric Society/SocieTY for Pediatric Research Abstract. 2006. CODEN. RCT. ISSN: CN-00711875. Unobtainable.
Tang S. F., Miller O. I. Inhaled nitric oxide during emergency neonatal transportation. J Paediatr Child Health. 1996;32(6):539-41. Article does not include infants born at less than 34 weeks gestation. [pmid: 9007787].
Tang S. F., Miller O. I. Low-dose inhaled nitric oxide for neonates with pulmonary hypertension. J Paediatr Child Health. 1996;32(5):419-23. Article does not include infants born at less than 34 weeks gestation. [pmid: 8933403].
Tavares A. P., Pimenta Junior A. G., Evora P. R. Basis for the therapeutic use of inhaled nitric oxide: Fundamentos para o uso terapeutico do oxido nitrico pela via inalatoria. Arq. Bras. Cardiol. 1995;64(1):45-52. Not written in English and cannot determine eligibility. [pmid: 7669012].
Ten Eick A. P., Gormley A. Phosphodiesterase inhibitors and persistent pulmonary hypertension of the newborn. Hosp. Pharm. 2004;39(9):831-834. No original data. Article does not address any of the Key Questions.
Tolsa J. F. [Physiologic aspects of lung circulation in adjustment to extra-uterine life]. Arch Pediatr. 2000;7(Suppl 2):269s-270s. Not written in English and cannot determine eligibility. [pmid: 10904736].
Tommasoni N., Gamba P. G., Midrio P., Biban P., Pettenazzo A., Zanon G. F., Guglielmi M. Congenital diaphragmatic hernia: the use of ECMO and other modern therapeutic strategies: Ernia congenita diaframmatica: impiego dell'ECMO e di altre moderne strategie terapeutiche. Pediatr Med Chir. 1996;18(3):295-300. Not written in English and cannot determine eligibility. [pmid: 8966131].
Trevisanuto D., Ferrarese P., Biban P., Cantarutti F., Zanardo V. Oxygenation response to NO in newborns with severe pulmonary hypertension [3]. Acta Paediatr. Int. J. Paediatr. 1996;85(11):1387. Article does not address any of the Key Questions.
Truffert P., Llado-Paris J., Mercier J. C., Dehan M., Breart G. Early inhaled nitric oxide in moderately hypoxemic preterm and term newborns with RDS: the RDS subgroup analysis of the Franco-Belgian iNO Randomized Trial. Eur J Pediatr. 2003;162(9):646-7. No abstractable data. [pmid: 12844257].
Truog W. E., Ballard P. L., Norberg M., Golombek S., Savani R. C., Merrill J. D., Parton L. A., Cnaan A., Luan X., Ballard R. A. Inflammatory markers and mediators in tracheal fluid of premature infants treated with inhaled nitric oxide. Pediatrics. 2007;119(4):670-678. No abstractable data. [pmid: 17403837].
Truog W. E., Pallotto E., Clark P., Banks B., Kaftan H. A., Ekekezie I. I., Norberg M., Ballard R. A. Interaction of endogenous endothelin-1 and inhaled nitric oxide in term and preterm infants. Clin. Sci. 2002;103(SUPPL. 48):294S-297S. Article does not address any of the Key Questions. [pmid: 12193107].
Tung B. J. The use of nitric oxide therapy in the transport of newborns with persistent pulmonary hypertension. Air Med J. 2001;20(5):10-1. No original data. Article does not include infants born at less than 34 weeks gestation. [pmid: 11552102].
Turanlahti M., Pesonen E., Pohjavuori M., Lassus P., Fyhrquist F., Andersson S. Plasma cyclic guanosine monophosphate reflecting the severity of persistent pulmonary hypertension of the newborn. Biol Neonate. 2001;80(2):107-12. No abstractable data. [pmid: 11509809].
Turbow R., Waffarn F., Yang L., Sills J., Hallman M. Variable oxygenation response to inhaled nitric oxide in severe persistent pulmonary hypertension of the newborn. Acta Paediatr. 1995;84(11):1305-8. Article does not include infants born at less than 34 weeks gestation. [pmid: 8580632].
Van Marter L. J. Epidemiology of bronchopulmonary dysplasia. Semin Fetal Neonatal Med. 2009;14(6):358-66. No original data. [pmid: 19783238].
Van Meurs K. P., Rhine W. D., Asselin J. M., Durand D. J., Peverini R., Dudell G., Butler S., Durand D., Asselin J., Van Meurs K., Rhine W. Response of premature infants with severe respiratory failure to inhaled nitric oxide. PEDIATR. PULMONOL. 1997;24(5):319-323. No abstractable data. [pmid: 9407564].
Vento M., Aguar M., Brugada M. Extremely premature infant: Overcoming inflammation and oxidative stress. Pediatr. Health. 2008;2(4):397-400. No original data.
Vieux R., Fresson J., Hascoet J. M., Blondel B., Truffert P., Roze J. C., Matis J., Thiriez G., Arnaud C., Marpeau L., Kaminski M. Improving perinatal regionalization by predicting neonatal intensive care requirements of preterm infants: an EPIPAGE-based cohort study. Pediatrics. 2006;118(1):84-90. Article does not address any of the Key Questions. [pmid: 16818552].
Von Buch Ch., Kachel W. Initiative application of nitric oxide in the treatment of persistent pulmonary hypertension of the newborn pretem baby - A case report: Inhalative stickoxid (NO)-anwendung zur behandlung der persistierenden pulmonalen hypertonie des fruhgeborenen fallberich. Monatsschr. Kinderheilkd. 1997;145(7):708-711. Not written in English and cannot determine eligibility. Article does not address any of the Key Questions.
Vosatka R. J. Persistent pulmonary hypertension of the newborn [3]. New Engl. J. Med. 2002;346(11):864. No original data. [pmid: 11893805].
Vyas J. R., Currie A. E., Shuker D. E., Field D. J., Kotecha S. Concentration of nitric oxide products in bronchoalveolar fluid obtained from infants who develop chronic lung disease of prematurity. Arch Dis Child Fetal Neonatal Ed. 1999;81(3):F217-20. Article does not include pre-term infants who were treated with inhaled nitric oxide. Article does not address any of the Key Questions. [pmid: 10525028].
Westrope C., Roberts N., Nichani S., Hunt C., Peek G. J., Firmin R. Experience with mobile inhaled nitric oxide during transport of neonates and children with respiratory insufficiency to an extracorporeal membrane oxygenation center. Pediatr Crit Care Med. 2004;5(6):542-6. Article does not include infants born at less than 34 weeks gestation. Article does not address any of the Key Questions. [pmid: 15530190].
Whitelaw A. Towards a molecular basis for intraventricular haemorrhage: nitric oxide and impaired cerebral autoregulation. Acta Paediatr. 2002;91(4):373-4. No original data. [pmid: 12061349].
Wilkowski J. [Inhaled nitric oxide in the therapy of acute hypoxemic respiratory failure of newborn]. Med Wieku Rozwoj. 2001;5(4):301-14. Not written in English and cannot determine eligibility. [pmid: 12004137].
Williams O., Hutchings G., Debieve F., Debauche C. Contemporary neonatal outcome following rupture of membranes prior to 25 weeks with prolonged oligohydramnios. Early Hum. Dev. 2009;85(5):273-277. No abstractable data. [pmid: 19108959].
Xiao Z. H., Andre P., Lacaze-Masmonteil T., Audibert F., Zupan V., Dehan M. Outcome of premature infants delivered after prolonged premature rupture of membranes before 25 weeks of gestation. Eur. J. Obstet. Gynecol. Reprod. Biol. 2000;90(1):67-71. No abstractable data. [pmid: 10767513].
Yamaguchi N., Togari H. A multicenter clinical retrospective study of inhaled nitric oxide in neonates. ACTA NEONATOL. JPN. 1996;32(3):464-471. Not written in English and cannot determine eligibility.
Yamaguchi N., Togari H., Takase M., Hattori S., Yamanami S., Hasegawa H., Hoshino R., Tamura M., Mimura S., Suzuki S., Futamura M., Aotani H., Sumi K., Kusuda S., Ichiba H., Yong-Kye L., Uetani Y., Nakao H., Higuchi R. A prospective clinical study on inhaled nitric oxide therapy for neonates in Japan. Pediatr Int. 2001;43(1):20-5. Article address Key Question 1 or 2 ONLY and is not a randomized controlled trial. [pmid: 11207994].
Yao C.-T., Wang J.-N., Lin C.-H., Yeh C.-N., Tai Y.-T., Wu M.-H., Wu J.-M. Prediction of outcome in infants with congenital diaphragmatic hernia or severe diaphragmatic eventration. Acta Paediatr. Taiwan. 2004;45(3):131-135. Article does not address any of the Key Questions. [pmid: 15493730].
Yao C.-T., Wang J.-N., Lin C.-H., Yeh C.-N., Tai Y.-T., Wu M.-H., Wu J.-M. Prediction of outcome in infants with congenital diaphragmatic hernia or severe diaphragmatic eventration. Acta Paediatr. Taiwan. 2004;45(3):131-135. Other reason. [pmid: 15493730].
Yeh T.-F. Persistent pulmonary hypertension in preterm infants with respiratory distress syndrome. Pediatr. Pulmonol. 2001;32(Suppl. 23):103-106. No original data. [pmid: 11886105].
Young J. D. The use of inhaled nitric oxide in the acute respiratory distress syndrome. Br J Hosp Med. 1997;57(4):126-7. No original data. [pmid: 9166368].
Yu V. Y. H. Persistent pulmonary hypertension in the newborn. Early Hum. Dev. 1993;33(3):163-175. No original data. [pmid: 8223312].
Zamakhshary M., Mah K., Mah D., Cameron B., Bohn D., Bass J., Scott L., Kim P. C. W. Physiologic predictors for the need for patch closure in neonatal congenital diaphragmatic hernia. Pediatr. Surg. Int. 2008;24(6):667-670. Article does not include infants born at less than 34 weeks gestation. [pmid: 18414876].
Zamakhshary M., Mah K., Mah D., Cameron B., Bohn D., Bass J., Scott L., Kim P. C. Physiologic predictors for the need for patch closure in neonatal congenital diaphragmatic hernia. Pediatr Surg Int. 2008;24(6):667-70. Article does not address any of the Key Questions. [pmid: 18414876].
Zecca E., De Luca D., Costa S., Marras M., Romagnoli C. Neonatal intensive care and outcomes of extremely preterm infants: Changes over a decade. Ital. J. Pediat. 2006;32(1):48-54. Other reason.
Zhan Q. Y. [The role of high frequency oscillatory ventilation in the treatment of acute respiratory distress syndrome]. Zhonghua Jie He He Hu Xi Za Zhi. 2007;30(10):740-1. Not written in English and cannot determine eligibility. [pmid: 18218202].
Ziebinski M., Walas W. The use of nitric oxide during transport of newborns with critical respiratory insufficiency: own experience, preliminary report: Wstepne doswiadczenia wlasne w stosowaniu tlenku azotu podczas transportu noworodkow z krytyczna niewydolnoscia oddechowa. Prz. Lek. 2002;59(Suppl 1):60-62. Not written in English and cannot determine eligibility. [pmid: 12108077].
Zorc J. J., Kanic Z. A cyanotic infant: True blue or otherwise?. Pediatr. Ann. 2001;30(10):597-601. No original data. [pmid: 11641851].