# Screen and Data Abstraction Forms

Abstract Review Form

Article Inclusion/Exclusion Form

Study Characteristics Form

Participant Characteristics Form

All Outcomes Form

Case Report Form

Risk of Bias Forms