# Detailed Electronic Database Search Strategies

Terms | Returns
MEDLINE Strategy
((“nitric oxide”[tiab] OR “nitric oxide”[mh] OR iNO[tiab]) AND (“infant, newborn”[mh] OR premature[tiab] OR preterm[tiab] OR prematurity[tiab])) NOT (Animal[mh] NOT Human[mh]) | 1747
EMBASE Strategy
(('nitric oxide':ab,ti OR 'nitric oxide'/exp OR 'ino':ab,ti) AND ('newborn'/exp OR 'newborn':ab,ti OR 'prematurity'/exp OR 'premature':ab,ti OR 'prematurity':ab,ti OR 'preterm':ab,ti)) NOT ([animals]/lim NOT [humans]/lim) | 2464
The Cochrane Central Register of Controlled Trials (CENTRAL)
((((nitric oxide):ti,ab,kw OR (iNO):ti,ab,kw) AND ((infant):ti,ab,kw OR (newborn):ti,ab,kw OR (premature):ti,ab,kw OR (preterm):ti,ab,kw)) NOT ((animals) NOT (humans))) | 260
Psycinfo Strategy
( TX “nitric oxide” or TX “iNO” ) and ( TX “infant, newborn” or TX “premature” or TX “preterm” or TX prematurity ) | 13