# List of Acronyms

AHRQ: Agency for Healthcare Research and Quality
ArtrCath: Arterial catheter
BPD: Bronchopulmonary dysplasia
BSID: Bayley scale of infant development
BW: Birth weight
CMV: Conventional mechanical ventilation
Congen: Congenital anomaly/malformation
CP: Cerebral palsy
CPAP: Continuous Positive Airway Pressure
DQ: Developmental quotient
Dshunting: Ductal Shunting
ECMO: Extracorporeal membrane oxygenation
EDC: Estimated date of confinement
F/U: Follow- up
FDA: Food and Drug Administration
FiO2: Fraction of Inspired Oxygen
g: grams
GA: Gestational age
GCAS: General conceptual ability
HFFI: High-frequency flow interruption
HFOV: High-frequency oscillatory ventilation
HFV: High-frequency ventilation
HRF: Hypoxemic respiratory failure
iNO: inhaled Nitric Oxide
intrprncyml: Intraparenchymal lesion
IPH: intraparenchymal hemorrhage
IQR: Inter-quartile range
IVH: Intraventricular Hemorrhage
JHU: Johns Hopkins University
KG: Kilograms
MAP: Mean airway pressure
MDI: Mental developmental index
mmHg: millimeters of mercury
NDI: Neurodevelopmental impairment
NEC: Necrotizing enterocolitis
NICU: Neonatal intensive care unit
NIH: National Institutes of Health
NO: Nitric oxide
NO_2_: Nitrogen dioxide
OI: Oxygenation Index
Oligho: Oligohydramnios
OMAR: Office of Medical Applications of Research
PDA: Patent Ductus Arteriosis
PDI: Physical developmental index
PMA: post menstrual age
PPHN: Persistent Pulmonary Hypertension of the Newborn
ppm: parts per million
Pulmhyp: Pulmonary hypoplasia
PVL: Periventricular leukomalacia
RCT: Randomized controlled trial
RDS: Respiratory distress syndrome
Respfail: Respiratory failure
ROP: Retinopathy of Prematurity
RX: treatment
SD: Standard deviation
Vent Support: Ventilation Support