# Acknowledgments

The EPC thanks Ritu Sharma, Brandyn Lau, and Rebecca Stainmann for their assistance with literature searching, database management, and project organization, and Brenda Zacharko for her assistance with budget matters and final preparations of the report.

We also extend our appreciation to the members of our Technical Expert Panel (TEP) and Peer Reviewers: Gerald M. Loughlin, M.D., T. Michael O'Shea, M.D., M.P.H., William Truog, M.D., Paul H. Lipkin, M.D., Brian Hanna, MDCM, John Zupancic, M.D., Sc.D., Brian Rogers, M.D., Lisa Askie, M.D.