# References and Included Studies

1 Strine TW, Hootman JM. US national prevalence and correlates of low back and neck pain among adults. Arthritis Rheum. May. 15. 2007;57(4):656-65. [pmid: 17471542].
2 Santaguia P, Gross A, Busse J, et al. Complementary and alternative medicine in back pain utilization report. [publisher-id: AHRQ Publication No. 09-E006]. Agency for Healthcare Research and Quality. 2009;177.
3 Furlan AD, van Tulder MW, Cherkin DC, et al. Acupuncture and dry-needling for low back pain. Cochrane Database Syst Rev. Jan. 25. 2005;(1):CD001351. [pmid: 15674876].
4 Santaguida PL, Gross A, Busse J, et al. Complementary and alternative medicine in back pain utilization report. [publisher-id: AHRQ Publication No. 09-E006]. Agency for Healthcare Research and Quality. 2009;177.
5 Bronfort G, Haas M, Evans R, et al. Evidence-informed management of chronic low back pain with spinal manipulation and mobilization. Spine J. 2008;8(1):213-25. [pmid: 18164469].
6 Mulligan BR. Manual therapy: Nags Snags MWMS etc. Wellington, NZ. Plane View Services. 1999.
7 Sagar SM, Dryden T, Wong RK. Massage therapy for cancer patients: a reciprocal relationship between body and mind. Curr Oncol. Apr. 2007;14(2):45-56. [pmid: 17576465].
8 Evers S, Goossens M, De VH, et al. Criteria list for assessment of methodological quality of economic evaluations: Consensus on Health Economic Criteria. Int J Technol Assess Health Care. 2005;21(2):240-5. [pmid: 15921065].
9 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. Jun. 1998;52(6):377-84. [pmid: 9764259].
10 van Tulder M, Furlan A, Bombardier C, et al. Updated method guidelines for systematic reviews in the cochrane collaboration back review group. Spine (Phila Pa 1976). Jun. 15. 2003;28(12):1290-9. [pmid: 12811274].
11 Owens DK, Lohr KN, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions-Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. 2009. Jul. 10.
12 Brozek J, Oxman A, Schünemann H. GRADEpro [software application]. 2008(Version 3.2 for Windows). 2008.
13 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
14 Furlan AD, Pennick V, Bombardier C, et al. 2009 updated method guidelines for systematic reviews in the Cochrane Back Review Group. Spine (Phila Pa 1976). Aug. 15. 2009;34(18):1929-41. [pmid: 19680101].
15 Moreno SG, Sutton AJ, Ades AE, et al. Assessment of regression-based methods to adjust for publication bias through a comprehensive simulation study. BMC Med Res Methodol. 2009;9:2. [pmid: 19138428].
16 Egger M, Davey SG, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. BMJ. Sep. 13. 1997;315(7109):629-34. [pmid: 9310563].
17 Aigner N, Fialka C, Stocker R, et al. [Acupuncture versus laser acupuncture in the treatment of whiplash injury - A prospective randomized study] [German]. Dtsch Z Akupunkt. 1999;42(1):4-12.
18 Aigner N, Fialka C, Stocker R, et al. [Whiplash injuries. A prospective, randomised comparison of conventional therapy and acupuncture]. Osteosynthese Int. 1998;6:15-20.
19 Aigner N, Stocker R. Whiplash injuries - a prospective, randomised comparison of conventional therapy, acupuncture, laseracupuncture and placebo-laseracupuncture. In 5th Annual Symposium on Complementary Healthcare. Focus Altern Complement Ther. 1998:180.
20 Alaksiev A, Kraev T. Postisometric relaxation versus high velocity low amplitude techniques in low back pain. Manuelle Medizin. Feb. 1996;34(1):14-7.
21 Aleksiev A, Kraev T. Postisometric relaxation versus high velocity low amplitude techniques in low back pain. J Orthop Med. 1994;16(2):38-41.
22 Brinkhaus B, Witt CM, Jena S, et al. Acupuncture in patients with chronic low back pain: a randomized controlled trial. [see comment]. Arch Intern Med. Feb. 27. 2006;166(4):450-7. [pmid: 16505266].
23 Brinkhaus B, Becker-Witt C. Efficacy of acupuncture in patients with chronic low back pain - the Acupuncture Randomised Trials (ART). Focus Altern Complement Ther. 2003;8(4):486-7.
24 Witt CM, Jena S, Selim D, et al. Pragmatic randomized trial evaluating the clinical and economic effectiveness of acupuncture for chronic low back pain. Am J Epidemiol. Sep. 1. 2006;164(5):487-96. [pmid: 16798792].
25 Witt C, Selim D, Reinhold T, et al. Cost-effectiveness of acupuncture in patients with headache, low back pain and osteoarthritis of the hip and the knee. 12th Annual Symposium on Complementary Health Care -- Abstracts. 19th-21st September 2005. Exeter, UK. Focus Altern Complement Ther. 2005:57-8.
26 Witt CM, Brinkhaus B, Reinhold T, et al. Efficacy, effectiveness, safety and costs of acupuncture for chronic pain - Results of a large research initiative. Acupunct Med. Suppl. 2006;24:S33-S39.
27 Carlsson CP, Sjolund BH. Acupuncture for chronic low back pain: a randomized placebo-controlled study with long-term follow-up. Clin J Pain. Dec. 2001;17(4):296-305. [pmid: 11783809].
28 Carlsson C P. Long-term pain relief after acupuncture for chronic low back pain- a placebo controlled study.[abstract]. In Seventh World Congress on Pain. Paris. 1993.
29 Cherkin DC, Eisenberg D, Sherman KJ, et al. Randomized trial comparing traditional Chinese medical acupuncture, therapeutic massage, and self-care education for chronic low back pain. Arch Intern Med. Apr. 23. 2001;161(8):1081-8. [pmid: 11322842].
30 Kalauokalani D, Cherkin DC, Sherman KJ, et al. Lessons from a trial of acupuncture and massage for low back pain: patient expectations and treatment effects. Spine. Jul. 1. 2001;26(13):1418-24. [pmid: 11458142].
31 Childs JD, Fritz JM, Flynn TW, et al. A clinical prediction rule to identify patients with low back pain most likely to benefit from spinal manipulation: a validation study. [see comment]. [summary for patients in Ann Intern Med. 2004 Dec 21;141(12):I39; PMID: 15611484]. Ann Intern Med. Dec. 21. 2004;141(12):920-8. [pmid: 15611489].
32 Childs JD. Validation of a clinical prediction rule to identify patients likely to benefit from spinal manipulation: A randomized clinical trial. [Thesis]. Pittsburg. PA University of Pittsburgh. 2003:296.
33 Childs JD, Flynn TW, Fritz JM. A perspective for considering the risks and benefits of spinal manipulation in patients with low back pain. Man Ther. Nov. 2006;11(4):316-20. [pmid: 16839800].
34 Fritz JM, Whitman JM, Childs JD. Lumbar spine segmental mobility assessment: an examination of validity for determining intervention strategies in patients with low back pain. Arch Phys Med Rehab. Sep. 2005;86(9):1745-52.
35 Whitman JM, Fritz JM, Childs JD. The influence of experience and specialty certifications on clinical outcomes for patients with low back pain treated within a standardized physical therapy management program. J Orthop Sports Phys Ther. Nov. 2004;34(11):662-72. [pmid: 15609487].
36 Childs J, D, Fritz J, et al. Risks associated with the failure to offer manipulation for patients with low back pain. J Man Manip Ther. 2004;(12):161-2.
37 Haake M, Muller HH, Schade-Brittinger C, et al. German Acupuncture Trials (GERAC) for chronic low back pain: randomized, multicenter, blinded, parallel-group trial with 3 groups. [erratum appears in Arch Intern Med. 2007 Oct 22;167(19):2072]. Arch Intern Med. Sep. 24. 2007;167(17):1892-8. [pmid: 17893311].
38 Endres HG, Victor N, Haake M, et al. [Acupuncture for the treatment of chronic knee and back pain.][German]. Deutsches Arzteblatt. 2007;104(3):A123-A130.
39 Ferreira ML, Ferreira PH, Latimer J, et al. Comparison of general exercise, motor control exercise and spinal manipulative therapy for chronic low back pain: A randomized trial. Pain. Sep. 2007;131(1-2):31-7. [pmid: 17250965].
40 Ferreira ML, Ferreira PH, Latimer J, et al. Relationship between spinal stiffness and outcome in patients with chronic low back pain. Man Ther. Feb. 2009;14(1):61-7. [pmid: 18164644].
41 Franke A, Gebauer S, Franke K, et al. [Acupuncture massage vs Swedish massage and individual exercise vs group exercise in low back pain sufferers--a randomized controlled clinical trial in a 2 x 2 factorial design]. [German]. Forsch Komplementarmed Klass Naturheilkd. Dec. 2000;7(6):286-93. [pmid: 11155022].
42 Franke A, Franke K, Gebauer S, et al. Acupuncture massage vs. Swedish massage and individual exercises vs. group exercises in low back pain sufferers: a randomised clinical trial in a 2 x 2-factorial design. Focus Altern Complement Ther. 2000;5(1):88-9.
43 Fryer G, Hodgson L. The effect of manual pressure release on myofascial trigger points in the upper trapezius muscle. J Bodywork Movement Ther. 2005;9(4):248-55.
44 Hodgson L, Fryer G. The effect of manual pressure release on myofascial trigger points in the upper trapezius muscle. Int J Osteopath Med. 2006;9(JUN):33.
45 Ga H, Choi JH, Park CH, et al. Acupuncture needling versus lidocaine injection of trigger points in myofascial pain syndrome in elderly patients--a randomised trial. Acupunct Med. Dec. 2007;25(4):130-6. [pmid: 18160923].
46 Ga H, Choi JH, Park CH, et al. Dry needling of trigger points with and without paraspinal needling in myofascial pain syndromes in elderly patients. J Altern Complement Med. Jul. 2007;13(6):617-24. [pmid: 17718644].
47 Gallacchi G, Muller W. [Acupuncture--does it contribute anything?]. [German]. Schweiz Rundsch Med Prax. May. 31. 1983;72(22):778-82. [pmid: 6224144].
48 Gallacchi G, Muller W, Plattner GR, et al. [Acupuncture and laser treatment in cervical and lumbar syndrome]. [German]. Schweiz Med Wochenschr. Sep. 12. 1981;111(37):1360-6. [pmid: 6457384].
49 Garvey TA, Marks MR, Wiesel SW. A prospective, randomized, double-blind evaluation of trigger-point injection therapy for low-back pain. Spine. Sep. 1989;14(9):962-4. [pmid: 2528826].
50 Garvey TA, Marks MR, Wiesel SW. A prospective randomized double-blind evaluation of trigger-point injection therapy for low-back pain. [Analysis by Blair S. Alden]. DC Tracts. Aug. 1990;2(4):230-5.
51 Giles LG, Muller R. Chronic spinal pain: a randomized clinical trial comparing medication, acupuncture, and spinal manipulation. [see comment]. Spine. Jul. 15. 2003;28(14):1490-502. [pmid: 12865832].
52 Muller R, Giles LG. Long-term follow-up of a randomized clinical trial assessing the efficacy of medication, acupuncture, and spinal manipulation for chronic mechanical spinal pain syndromes. J Manipulative Physiol Ther. Jan. 2005;28(1):3-11. [pmid: 15726029].
53 Grant DJ, Bishop-Miller J, Winchester DM, et al. A randomized comparative trial of acupuncture versus transcutaneous electrical nerve stimulation for chronic back pain in the elderly. Pain. Jul. 1999;82(1):9-13. [pmid: 10422654].
54 Grant DJ, Bishop-Miller J, Winchester D, et al. A randomised comparative trial of acupuncture versus TENS for chronic back pain in the elderly.[abstract]. Age Ageing. Suppl 1. 1998;27:13. [pmid: 9504361].
55 Hadler NM, Curtis P, Gillings DB, et al. A benefit of spinal manipulation as adjunctive therapy for acute low-back pain: a stratified controlled trial. Spine. Sep. 1987;12(7):703-6.
56 Hancock MJ, Maher CG, Latimer J, et al. Assessment of diclofenac or spinal manipulative therapy, or both, in addition to recommended first-line treatment for acute low back pain: a randomised controlled trial. [see comment]. Lancet. Nov. 10. 2007;370(9599):1638-43. [pmid: 17993364].
57 Hoiriis KT, Pfleger B, McDuffie FC, et al. A randomized clinical trial comparing chiropractic adjustments to muscle relaxants for subacute low back pain. J Manipulative Physiol Ther. Jul. 2004;27(6):388-98. [pmid: 15319761].
58 Hadler N, Curtis P, Gillings D, et al. A benefit of spinal manipulation as adjunctive therapy for acute low-back pain: A stratified controlled trial. Manuelle Medizin. 1990;(28):2-6.
59 Hancock MJ, Maher CG, Latimer J, et al. Independent evaluation of a clinical prediction rule for spinal manipulative therapy: a randomised controlled trial. Eur Spine J. Jul. 2008;17(7):936-43. [pmid: 18427840].
60 Badgett R. Adjunctive diclofenac and spinal manipulation did not speed recovery of acute low back pain. Evid Based Med. 2008;13(3):75. [pmid: 18515622].
61 Hoiriis KT, Pfleger B, McDuffie FC, et al. A randomized clinical trial comparing chiropractic to conservative medical care for subacute low back pain. Eur J Chiropr. 2002;49(1):101.
62 Hoving JL, de Vet HC, Koes BW, et al. Manual therapy, physical therapy, or continued care by the general practitioner for patients with neck pain: long-term results from a pragmatic randomized clinical trial. Clin J Pain. May. 2006;22(4):370-7. [pmid: 16691091].
63 Korthals de Bos I, Hoving JL, van Tulder MW, et al. Cost effectiveness of physiotherapy, manual therapy, and general practitioner care for neck pain: economic evaluation alongside a randomised controlled trial. [see comment]. BMJ. Apr. 26. 2003;326(7395):911. 2003. [pmid: 12714472].
64 Kothals-de-Bos I, Hoving J, van TM, et al. Cost effectiveness of physiotherapy, manual therapy and general practitioner care for neck pain. Economic evaluation alongside a randomized controlled trial. Manuelle Medizin. Oct. 2005;43(5):311-8.
65 Hurwitz EL, Morgenstern H, Harber P, et al. A randomized trial of chiropractic manipulation and mobilization for patients with neck pain: clinical outcomes from the UCLA neck-pain study. [see comment]. Am J Public Health. Oct. 2002;92(10):1634-41. [pmid: 12356613].
66 Hurwitz EL, Morgenstern H, Kominski GF, et al. A randomized trial of chiropractic and medical care for patients with low back pain: eighteen-month follow-up outcomes from the UCLA low back pain study. Spine. Mar. 15. 2006;31(6):611-21. [pmid: 16540862].
67 Hurwitz EL, Goldstein MS, Morgenstern H, et al. The impact of psychosocial factors on neck pain and disability outcomes among primary care patients: Results from the UCLA neck pain study. Disabil Rehabil. 2006;28(21):1319-29. [pmid: 17083180].
68 Hurwitz EL, Morgenstern H, Vassilaki M, et al. Adverse reactions to chiropractic treatment and their effects on satisfaction and clinical outcomes among patients enrolled in the UCLA Neck Pain Study. [see comment]. J Manipulative Physiol Ther. Jan. 2004;27(1):16-25. [pmid: 14739870].
69 Hurwitz EL, Morgenstern H, Vassilaki M, et al. Frequency and clinical predictors of adverse reactions to chiropractic care in the UCLA neck pain study. [see comment]. Spine. Jul. 1. 2005;30(13):1477-84. [pmid: 15990659].
70 Hertzman-Miller RP, Morgenstern H, Hurwitz EL, et al. Comparing the satisfaction of low back pain patients randomized to receive medical or chiropractic care: results from the UCLA low-back pain study. Am J Public Health. Oct. 2002;92(10):1628-33. [pmid: 12356612].
71 Hurwitz EL, Morgenstern H, Yu F. Satisfaction as a predictor of clinical outcomes among chiropractic and medical patients enrolled in the UCLA low back pain study. Spine. Oct. 1. 2005;30(19):2121-8. [pmid: 16205336].
72 Kominski GF, Heslin KC, Morgenstern H, et al. Economic evaluation of four treatments for low-back pain: results from a randomized controlled trial. [see comment]. Med Care. May. 2005;43(5):428-35. [pmid: 15838406].
73 Goldstein MS, Morgenstern H, Hurwitz EL, et al. The impact of treatment confidence on pain and related disability among patients with low-back pain: results from the University of California, Los Angeles, low-back pain study. Spine J. Nov. 2002;2(6):391-9. [pmid: 14589256].
74 Hurwitz EL, Morgenstern H, Harber P, et al. A randomized trial of medical care with and without physical therapy and chiropractic care with and without physical modalities for patients with low back pain: 6-month follow-up outcomes from the UCLA low back pain study. [see comment]. Spine. Oct. 15. 2002;27(20):2193-204. [pmid: 12394892].
75 Hurwitz EL, Morgenstern H, Harber P, et al. The effectiveness of physical modalities among patients with low back pain randomized to chiropractic care: Findings from the UCLA low back pain study. J Manipulative Physiol Ther. 2002;25(1):10-20. [pmid: 11898014].
76 Hurwitz EL, Morgenstern H, Harber PI, et al. Effectiveness of physical modalities among low back pain patients randomized to chiropractic care: findings from the UCLA low-back pain study. Eur J Chiropr. 2002;49(1):102-3.
77 Irnich D, Behrens N, Molzen H, et al. Randomised trial of acupuncture compared with conventional massage and “sham” laser acupuncture for treatment of chronic neck pain. [see comment]. BMJ. Jun. 30. 2001;322(7302):1574-8. [pmid: 11431299].
78 Irnich D. Randomised, placebo, controlled, multicentre trial of acupuncture for the treatment of chronic neck pain. Dtsch Z Akupunkt. 2000;43(1):40.
79 Konig A, Radke S, Molzen H, et al. [Randomised trial of acupuncture compared with conventional massage and “sham” laser acupuncture for treatment of chronic neck pain - range of motion analysis]. [German]. Z Orthop Ihre Grenzgeb. Jul. 2003;141(4):395-400. [pmid: 12928995].
80 Irnich D, Behrens N, Gleditsch JM, et al. Immediate effects of dry needling and acupuncture at distant points in chronic neck pain: results of a randomized, double-blind, sham-controlled crossover trial. Pain. Sep. 2002;99(1-2):83-9. [pmid: 12237186].
81 Jull GA, Stanton WR. Predictors of responsiveness to physiotherapy management of cervicogenic headache. Cephalalgia. Feb. 2005;25(2):101-8. [pmid: 15658946].
82 Irnich D, Behrens N, ea. Abstract of Immediate effects of dry needling and acupuncture at distant points in chronic neck pain: results of a randomized, double-blind, sham- controlled crossover trial. Complement Ther Med. 2002;10(2):109.
83 Jull G, Trott P, Potter H, et al. A randomized controlled trial of exercise and manipulative therapy for cervicogenic headache. Spine. Sep. 1. 2002;27(17):1835-43. [pmid: 12221344].
84 Koes BW, Bouter LM, van MH, et al. A blinded randomized clinical trial of manual therapy and physiotherapy for chronic back and neck complaints: physical outcome measures. [see comment]. J Manipulative Physiol Ther. Jan. 1992;15(1):16-23. [pmid: 1531487].
85 Koes BW, Bouter LM, van MH, et al. A randomized clinical trial of manual therapy and physiotherapy for persistent back and neck complaints: subgroup analysis and relationship between outcome measures. [see comment]. J Manipulative Physiol Ther. May. 1993;16(4):211-9. [pmid: 8340715].
86 Koes BW, Bouter LM, van MH, et al. Randomised clinical trial of manipulative therapy and physiotherapy for persistent back and neck complaints: results of one year follow up. [see comment]. BMJ. Mar. 7. 1992;304(6827):601-5. [pmid: 1532760].
87 Koes BW, Bouter LM, van MH, et al. Randomised clinical trial of manual therapy and physiotherapy for persistent back and neck complaints. Ned Tijdschr Man Ther. 1992;11(2):7-12.
88 Lehmann TR, Russell DW, Spratt KF. The impact of patients with nonorganic physical findings on a controlled trial of transcutaneous electrical nerve stimulation and electroacupuncture. Spine. Sep. 1983;8(6):625-34. [pmid: 6228019].
89 Lewis M, James M, Stokes E, et al. An economic evaluation of three physiotherapy treatments for non-specific neck disorders alongside a randomized trial. Rheumatology. Nov. 2007;46(11):1701-8. [pmid: 17956916].
90 Little P, Lewith G, Webley F, et al. Randomised controlled trial of Alexander technique lessons, exercise, and massage (ATEAM) for chronic and recurrent back pain. BMJ. 2008;337:a884. 2008.:a884, 2008. [pmid: 18713809].
91 Lehmann TR, Russell DW, Spratt KF, et al. Efficacy of electroacupuncture and TENS in the rehabilitation of chronic low back pain patients. Pain. Sep. 1986;26(3):277-90. [pmid: 2946016].
92 Dziedzic K, Hill J, Lewis M, et al. Effectiveness of manual therapy or pulsed shortwave diathermy in addition to advice and exercise for neck disorders: a pragmatic randomized controlled trial in physical therapy clinics. Arthrit Rheum. Apr. 15. 2005;53(2):214-22.
93 Little P, Lewith G, Webley F, et al. Randomised controlled trial of Alexander technique lessons, exercise, and massage (ATEAM) for chronic and recurrent back pain. Br J Sports Med. Dec. 2008;42(12):965-8. [pmid: 19096019].
94 Hollinghurst S, Sharp D, Ballard K, et al. Randomised controlled trial of Alexander technique lessons, exercise, and massage (ATEAM) for chronic and recurrent back pain: economic evaluation. BMJ. 2008;337:a2656. [pmid: 19074232].
95 Meade TW, Dyer S, Browne W, et al. Low back pain of mechanical origin: randomized comparison of chiropractic and hospital outpatient treatment. J Orthop Sports Phys Ther. 1991;13(6):278-87. [pmid: 18784399].
96 Meade TW, Dyer S, Browne W, et al. Randomised comparison of chiropractic and hospital outpatient management for low back pain: results from extended follow up. [see comment]. BMJ. Aug. 5. 1995;311(7001):349-51. [pmid: 7640538].
97 Meade TW, Dyer S, Browne W, et al. Low back pain of mechanical origin: randomised comparison of chiropractic and hospital outpatient treatment. [see comment]. BMJ. Jun. 2. 1990;300(6737):1431-7. [pmid: 2143092].
98 Meade TW, Dyer S, Browne W, et al. Low back pain of mechanical origin: randomized comparison of chiropractic and hospital outpatient treatment. Er J Chiropract. Sep. 1990;38(3):92-107.
99 Molsberger AF, Mau J, Pawelec DB, et al. Does acupuncture improve the orthopedic management of chronic low back pain--a randomized, blinded, controlled trial with 3 months follow up. [see comment]. Pain. Oct. 2002;99(3):579-87. [pmid: 12406534].
100 Molsberger A, Winkler J, Schneider S, et al. Acupuncture and conventional orthopedic pain treatment in the management of chronic low back pain - a prospective randomised and controlled clinical trial. Issls. 1998;(June):87.
101 Pope MH, Phillips RB, Haugh LD, et al. A prospective randomized three-week trial of spinal manipulation, transcutaneous muscle stimulation, massage and corset in the treatment of subacute low back pain. Spine. Nov. 15. 1994;19(22):2571-7. [pmid: 7855683].
102 Hsieh CY, Phillips RB, Adams AH, et al. Functional outcomes of low back pain: comparison of four treatment groups in a randomized controlled trial. [see comment]. J Manipulative Physiol Ther. Jan. 1992;15(1):4-9. [pmid: 1531488].
103 Pope M. A prospective randomized three week trial of spinal manipulation, transcutaneous muscle stimulation, massage and corset in the treatment of subacute low back pain. Proc Int Conf Spinal Manipulation. 1993:109-10.
104 Rupert RL, Thompson P, Wagon R. Chiropractic adjustments: Results of a controlled clinical trial in Egypt. ICA Rev. May. 1985;41(3):58-60.
105 Rupert R, Wagon R, Thompson P. Chiropractic adjustments in the treatment of low back pain: preliminary results of a controlled clinical trial in Egypt [reprint]. Int Rev Chiropract. 1985;41(1):58-9.
106 Seidel U, Uhlemann C. [A randomised controlled double-blind trial comparing dosed lasertherapy on acupuncture points and acupuncture for chronic cervical syndrome]. [German]. Dtsch Z Akupunkt. 2002;45(4):258-69.
107 Seidel U. Acupuncture versus laser acupuncture for neck pain. Focus Altern Complement Ther. 2003;8(3):259-30.
108 Sims-Williams H, Jayson MI, Young SM, et al. Controlled trial of mobilisation and manipulation for low back pain: hospital patients. BMJ. Nov. 24. 1979;2(6201):1318-20. [pmid: 160266].
109 Jayson MI, Sims-Williams H, Young S, et al. Mobilization and manipulation for low-back pain. Spine. Jul. 1981;6(4):409-16. [pmid: 6456557].
110 Thomas KJ, MacPherson H, Ratcliffe J, et al. Longer term clinical and economic benefits of offering acupuncture care to patients with chronic low back pain. Health Technol Assess. 2005;9(32):1-109.
111 Thomas KJ, MacPherson H, Thorpe L, et al. Randomised controlled trial of a short course of traditional acupuncture compared with usual care for persistent non-specific low back pain. [see comment]. BMJ. Sep. 23. 2006;333(7569):623. 2006. [pmid: 16980316].
112 Ratcliffe J, Thomas KJ, MacPherson H, et al. A randomised controlled trial of acupuncture care for persistent low back pain: cost effectiveness analysis. [see comment]. BMJ. Sep. 23. 2006;333(7569):626. 2006. [pmid: 16980315].
113 Thomas K, MacPherson H, Ratcliffe J, et al. A short course of acupuncture is a cost-effective intervention for low back pain in primary care. Results from a pragmatic randomised controlled.[record]. Cochrane Library. 2009;(4):CN-00519332.
114 Thomas K, Thorpe L, MacPherson H. Preliminary findings from a pragmatic randomised controlled trial demonstrate acceptability of acupuncture as a treatment for low back pain. Clin Acupunct Orient Med. 2003;4(1):56.
115 Thorpe L, Thomas KJ, Fitter M, et al. Acupuncture in the management of persistent low back pain: findings to date of a pragmatic, randomised controlled trial. Focus Altern Complement Ther. 2002;7(1):113.
116 Thorpe L, Thomas K, Fitter M, et al. Early results from a pragmatic randomised controlled trial demonstrate acceptability and potential effectiveness of acupuncture as a treatment for low back pain [abstract]. The Challenge of Collaboration Proceedings of the 18th Annual Meeting of the International Society of Technology Assessment in Health Care. Jun 9 12 2002. 2002:204.
117 MacPherson H. Acupuncture and low back pain: Results from a pragmatic randomised controlled trial. J Altern Complement Med. 2004;10(1):204-5.
118 MacPherson H, Thomas K, Brazier J, et al. Longer term clinical and economic benefits of offering acupuncture to patients with chronic low back pain assessed as suitable for primary care management - 3 month clinical outcomes from a controlled trial of 241 patients. Acupunct Med. 2002;20(3-Feb):121.
119 Triano JJ, McGregor M, Hondras MA, et al. Manipulative therapy versus education programs in chronic low back pain. Spine. Apr. 15. 1995;20(8):948-55. [pmid: 7644961].
120 Triano J. A randomised controlled clinical trial of manipulation for chronic low back pain patients.[Abstract]. J Manipulative Physiol Ther. 1994;17(4):291.
121 Tsukayama H, Yamashita H, Amagai H, et al. Randomised controlled trial comparing the effectiveness of electroacupuncture and TENS for low back pain: a preliminary study for a pragmatic trial. Acupunct Med. Dec. 2002;20(4):175-80. [pmid: 12512791].
122 Tsukayama H, Yamashita H, Hirachi S, et al. Do we need placebo acupuncture in randomised controlled trials? A preliminary study on electro-acupuncture for low back pain. Focus Altern Complement Ther. 2000;5(1):103.
123 UK BEAM Trial Team. United Kingdom back pain exercise and manipulation (UK BEAM) randomised trial: effectiveness of physical treatments for back pain in primary care. [see comment]. BMJ. Dec. 11. 2004;329(7479):1377. 2004. [pmid: 15556955].
124 Farrin A, Russell I, Torgerson D, et al. Differential recruitment in a cluster randomized trial in primary care: the experience of the UK back pain, exercise, active management and manipulation (UK BEAM) feasibility study. Clinical Trials. 2005;2(2):119-24. [pmid: 16279133].
125 UK BEAM Trial Team. United Kingdom back pain exercise and manipulation (UK BEAM) randomised trial: cost effectiveness of physical treatments for back pain in primary care.[see comment]. BMJ. Dec. 11. 2004;329(7479):1381. 2004. [pmid: 15556954].
126 Venancio RA, Alencar FG, Zamperini C. Different substances and dry-needling injections in patients with myofascial pain and headaches. Cranio. Apr. 2008;26(2):96-103. [pmid: 18468269].
127 Venancio RA, Alencar FG Jr, Zamperini C. Botulinum toxin, lidocaine, and dry-needling injections in patients with myofascial pain and headaches. Cranio. Jan. 2009;27(1):46-53. [pmid: 19241799].
128 White P, Lewith G, Prescott P, et al. Acupuncture versus placebo for the treatment of chronic mechanical neck pain: a randomized, controlled trial. [see comment]. [summary for patients in Ann Intern Med. 2004 Dec 21;141(12):I26; PMID: 15611483]. Ann Intern Med. Dec. 21. 2004;141(12):911-9. [pmid: 15611488].
129 White PJ. Abstract of The efficacy of acupuncture for the treatment of chronic mechanical neck pain - a randomised, controlled, single blind trial. Complement Ther Med. 2002;10(2):113.
130 Willich SN, Reinhold T, Selim D, et al. Cost-effectiveness of acupuncture treatment in patients with chronic neck pain. Pain. Nov. 2006;125(1-2):107-13. [pmid: 16842918].
131 Witt CM, Jena S, Brinkhaus B, et al. Acupuncture for patients with chronic neck pain. Pain. Nov. 2006;125(1-2):98-106. [pmid: 16781068].
132 Becker-Witt C, Jena S, Brinkhaus B, et al. Acupuncture in patients with chronic neck pain - the Acupuncture in Routine Care (ARC) Study. Focus Altern Complement Ther. 2004;(9):5-6.
133 Walsh N. Study backs acupuncture for headaches, neck pain. Ob/Gyn News. 2005;(February).
134 Yuan X, Liu C, Wang J. Clinical observation of elongated needle treatment of lumbar intervertebral disc prolapse. Int J Clin Acupunct. 2006;15(2):81-3.
135 Yuan XL, Liu C, Chen J. Clinical observation on the elongated needle for treatment of prolapse of lumbar intervertebral disk] [Chinese]. Zhongguo Zhen Jiu. 2004;24(3):171-2.
136 Yuan J, Purepong N, Hunter RF, et al. Different frequencies of acupuncture treatment for chronic low back pain: an assessor-blinded pilot randomised controlled trial. Complement Ther Med. Jun. 2009;17(3):131-40. [pmid: 19398066].
137 Yuan J, Purepong N, Kerr DP, et al. A pilot randomised controlled trial comparing different frequencies of acupuncture for chronic low back pain. 13th Annual Symposium on Complementary Health Care. 12th-14th December, 2006. University of Exeter, UK. Focus Altern Complement Ther. 2006:57-8.
138 Zhang B-M, Wu Y-C, Shao P, et al. Electro-acupuncture therapy for lumbar intervertebral disc protrusion: A randomized controlled study. [Chinese]. J Clin Tissue Eng Res. 2008;12(2):353-5.
139 Zhang BM, Wu YC, Shao P. Treatment of lumbar intervertebral disk herniation with electric acupuncture] [Chinese]. Zhen Jiu T. 2007;5(4):216-20.
140 Giles LG, Muller R. Chronic spinal pain syndromes: a clinical pilot trial comparing acupuncture, a nonsteroidal anti-inflammatory drug, and spinal manipulation. [see comment]. J Manipulative Physiol Ther. Jul. 1999;22(6):376-81. [pmid: 10478769].
141 Mendelson G, Selwood TS, Kranz H, et al. Acupuncture treatment of chronic back pain. A double-blind placebo-controlled trial. Am J Med. Jan. 1983;74(1):49-55. [pmid: 6217745].
142 Mendelson G, Kidson MA, Loh ST, et al. Acupuncture analgesia for chronic low back pain. Clin Exp Neurol. 1978;15:182-5. 1978.:182-5. [pmid: 158752].
143 Sator-Katzenschlager SM, Scharbert G, Kozek-Langenecker SA, et al. The short- and long-term benefit in chronic low back pain through adjuvant electrical versus manual auricular acupuncture. [see comment]. Anesth Analg. 2004;98(5):1359-64. [pmid: 15105215].
144 Gunn CC, Milbrandt WE, Little AS, et al. Dry needling of muscle motor points for chronic low-back pain: a randomized clinical trial with long-term follow-up. Spine. May. 1980;5(3):279-91. [pmid: 6446774].
145 Edelist G, Gross AE, Langer F. Treatment of low back pain with acupuncture. Can Anaesth Soc J. 1976;23(3):303-6. [pmid: 132988].
146 Chen MR, Wang P, Cheng G, et al. [Effect of warming needle moxibustion on pain threshold in the patient of sciatica]. [Chinese]. Zhongguo Zhen Jiu. Dec. 2005;25(12):831-3. [pmid: 16419700].
147 Liang SY. [Observation on therapeutic effect of tendon-muscle picking therapy on myofascitis of back]. [Chinese]. Zhongguo Zhen Jiu. Aug. 2008;28(8):621-2. [pmid: 18767591].
148 Tang HS. [Comparative observation of corresponding channel point selection for treatment of prolapse of lumbar intervertebral disc]. [Chinese]. Zhongguo Zhen Jiu. Aug. 2008;28(8):582-4. [pmid: 18767583].
149 She RP. [Observation on therapeutic effect of deeply needling Qiangji 4 points on prolapse of lumbar intervertebral disc]. [Chinese]. Zhongguo Zhen Jiu. May. 2008;28(5):341-4. [pmid: 18652325].
150 Mu JP, Cheng JM, Ao JB, et al. [Multiple central clinical test of electroacupuncture at Jiaji (EX-B 2) combined with laser needle-knife for treatment of lumbar disc herniation]. [Chinese]. Zhongguo Zhen Jiu. Aug. 2007;27(8):553-6. [pmid: 17853748].
151 Wu MQ. [Clinical observation on selection of acupoints on the same nerve segment for treatment of prolapxe of lumber intervertebral disc]. [Chinese]. Zhongguo Zhen Jiu. Jul. 2007;27(7):497-9. [pmid: 17722827].
152 He XW, Huang JH, Zeng LY. [Observation on the therapeutic effect of warming needle moxibustion on prolapse of lumbar intervertebral disc]. [Chinese]. Zhongguo Zhen Jiu. Apr. 2007;27(4):264-6. [pmid: 17585670].
153 Zhang Y, Chen F, Wu S. [Clinical observation on O3 acupoint injection for treatment of low back pain]. [Chinese]. Zhongguo Zhen Jiu. Feb. 2007;27(2):115-6. [pmid: 17370494].
154 Zhou YL, Zhang SQ, Sun GS, et al. [Clinical observation on ankle-three-needle for treatment of nerve root pain of prolapse of lumbar intervertebral disc]. [Chinese]. Zhongguo Zhen Jiu. Dec. 2006;26(12):847-50. [pmid: 17313003].
155 Tsui ML, Cheing GL. The effectiveness of electroacupuncture versus electrical heat acupuncture in the management of chronic low-back pain. J Altern Complement Med. Oct. 2004;10(5):803-9. [pmid: 15650469].
156 Fu ZH, Chen XY, Lu LJ, et al. Immediate effect of Fu’s subcutaneous needling for low back pain. Chin Med J. Jun. 5. 2006;119(11):953-6. [pmid: 16780777].
157 Huang G-F, Zhang H-X, Zhang T-F, et al. Time-dependent analgesic effect of electroacupuncture at Jiaji acupoint in patients with lumbar disc herniation and its intervention on related factors of plasma. [Chinese]. Chinese J Clin Rehab. 2006;10(43):1-6.
158 Wang N. [Acupuncture plus traction therapy for lumbar intervertebral disc protrusion: Curative effect observation]. [Chinese]. J Clin Tissue Eng Res. 2007;11(25):4945-8.
159 Li D-J, Wang J, Gao Q, et al. Complementary effect of traction rotatory manipulation of lumbar spine and silver needle heat conductive treatment on lumbar disc herniation. [Chinese]. Chinese J Clin Rehab. 2006;10(47):8-11.
160 Huang S, Zhan H, Shi Y. Clinical lumbar function-recovering effect of different electroacupuncture points on lumbar intervertebral disc herniation. [Chinese]. Chinese J of Rehab Med. 2006;21(6):497-500.
161 Wang Y-Q, Tang L-X, Pan C-Q. [Amelioration of ventral acupuncture therapy on the pain symptom in patients with lumbar disc herniation]. [Chinese]. Chinese J Clin Rehab. 2005;9(38):122-3.
162 Lian N, Liu J-B, Torres F, et al. Improvement of dermal needle and body acupuncture on pain due to lumbar strain and hyperplastic spondylitis. Chinese J Clin Rehab. 2005;9(42):161-3.
163 Li N, Wu B, Wang C-W. Comparison of acupuncture-moxibustion and physiotherapy in treating chronic non-specific low back pain. [Chinese]. Chinese J Clin Rehab. 2005;9(2):186-7.
164 Guo W, Zhang H-J, Lin W-E. Effect of different acupuncture therapies in improving functional disturbance of waist and limbs in patients with multiple lumbar disc herniation at different stages. [Chinese]. Chinese J Clin Rehab. 2005;9(2):184-5.
165 Chen X. Comparative study on acupuncture needling methods for sciatica: Routine needling vs. Point-to-point penetration and deep puncture. Am J Acupunct. 1998;26(1):37-41.
166 Jia C, Jiang G-M, Liu D-G. Effect of deep acupuncture at jiaji acupoint and acupoint-injection on lumbar disc herniation and the influence on the levels of interleukins. [Chinese]. Chinese J Clin Rehab. 2004;8(17):3324-6.
167 Cao W, Wang J. Curative effect of acute lumbago with different acupuncture and moxibustion methods. Int J Clin Acupunct. 2001;12(1):21-9.
168 Long WJ. Acupuncture treatment of acute lumbar sprain: a controlled study in 238 patients. Int J Clin Acupunct. 2000;11(1):61-4.
169 Lai YZ, Zhuang LX, Zhuang ZJ, et al. [Clinical observations on needling xi-cleft points as a main treatment for the acute stage of lumbar intervertebral disc protrusion]. Shanghai J Acupunct Moxibustion. 2004;23(9):22-4.
170 Ye Z. [Clinical studies on the treatment of lumbar intervertebral disc protrusion with a needle knife as the main method] [Chinese]. Shanghai J Acupunct Moxibustion. 2004;23(2):11-2.
171 Ding XIY. [Clinical observations on the treatment of intervertebral disc protrusion with contralateral acupuncture]. Shanghai J Acupunct Moxibustion. 2002;21(4):24.
172 Zhang Z. [Observations on the curative effect of acupuncture and massage on lumbar intervertebral disc protrusion]. Shanghai J Acupunct Moxibustion. 2002;21(3):15.
173 Ye D, Zhu H. [Treat lumbar intervertebral disc protrusion( (LIDP) by electric acupuncture traction and tuina in different stages]. J Zhejiang Coll Trad Chinese Med. 2002;26(3):60.
174 Yu WH, Fan WM, Cai H, et al. Clinical and mechanical studies on treatment of lumbago by needing WEIZHONG (BL40) point. Chinese Acupunct Moxibustion. 1997;17(8):503-4.
175 He RY. Clinical observation on treatment of lumbago due to cold-dampness by warm-acupuncture plus Chinese medicine. Chinese Acupunct Moxibustion. 1997;17(5):279-80.
176 Wang ZX. [Clinical observation on electroacupuncture at acupoints for treatment of senile radical sciatica]. Zhongguo Zhen Jiu. Feb. 2009;29(2):126-8. [pmid: 19391537].
177 Yao Z. Observations on the curative effect of acupuncture and moxibustion on lumbar intervertebral disc protrusion] [Chinese]. Shanghai J Acupunct Moxibustion. 2007;26(2):25-6.
178 Chen XY. Observations on the efficacy of deep acupuncture of Jiaji points for treating lumbar intervertebral disc protrusion] [Chinese]. Shanghai J Acupunct Moxibustion. 2007;26(3):21-2.
179 Zeng YF. [Clinical observations on the treatment of 67 lumbar intervertebral disc protrusions by abdomen acupuncture] [Chinese]. Shanghai J Acupunct Moxibustion. 2007;26(9):16-7.
180 Zhong B. Treatment of lumbar intervertebral disc protrusion by abdominal acupuncture plus traction] [Chinese]. Shanghai J Acupunct Moxibustion. 2006;25(6):19-20.
181 Qu Y, Mei XD, Qu H. [Control observation of therapeutic effects on syndrome of the 3rd lumbar transverse process with thick silver warming needling and electric acupuncture][Chinese]. World J Acupunct-Moxibustion. 2006;16(3):19-22.
182 Ye L, Hu YM, Zhang SL. [Clinical study on treatment of prolapse of lumbar intervertebral disc with hypodermic catgut embedding therapy][Chinese]. Chinese Acupunct Moxibustion. 2004;24(4):245-7.
183 Wang Y. [Point-through-point acupuncture treatment of 66 patients with third lumbar vertebra transverse process syndrome] [Chinese]. Shanghai J Acupunct Moxibustion. 2004;23(2):9-10.
184 Zhou ZT. [Observations on the effect of abdominal acupuncture in treating 42 cases of lumbar intervertebral disc protrusion] [Chinese]. Shanghai J Acupunct Moxibustion. 2004;23(2):13-4.
185 Cui J, Xiang K, Liang YY. Scalp acupuncture and massage for treatment of prolapse of lumbar intervertebral disc and effects on immune functions] [Chinese]. Chinese Acupunct Moxibustion. 2004;24(7):445-8.
186 Wu YC. [Clinical observations on electroacupuncture treatment of lumbar intervertebral disc protrusion] [Chinese]. Shanghai J Acupunct Moxibustion. 2004;23(5):15-7.
187 Wu Y, Liao J, Li Q. [Clinical observation on abdominal acupuncture for treatment of 114 cases of prolapse of lumbar intervertebral disc] [Chinese]. Chinese Acupunct Moxibustion. 2004;24(11):750-2.
188 Zhu Q, Li SL, Min XJ. [Clinical study on treatment of prolapse of lumbar intervertebral disc by acup-moxibustion combined with autonomic traction][Chinese]. Chinese Acupunct Moxibustion. 2003;23(10):571-3.
189 Ding YD. [Fly-probing-acupoint manipulation as a main treatment for lumbago] [Chinese]. Shanghai J Acupunct Moxibustion. 1998;17(5):25-6.
190 Zhou Y. [Observation of the effectiveness of prolapse of lumbar intervebral disc treated by warm needling insert Jiaji points](in Chineses). Shanghai J Acupunct Moxibustion. 1998;17(2):25.
191 Xia FX. [41 cases of prolapse of lumbar intervertebral disc treated by complex treatment] [Chinese]. Shanghai J Acupunct Moxibustion. 1997;16(5):17.
192 Li Q, Shang W. The effect of acupuncture plus cupping on 78 cases with lumbago. Hebei Chinese Trad Med. 1997;19(5):28.
193 Luo S. A combined treatment of scalp acupuncture and traction in 108 cases of prolapse of the lumbar intervertebral disc. J Tradit Chin Med. Sep. 2007;27(3):178-9. [pmid: 17955652].
194 Peng Y,Y, Huang Y, et al. [Clinical study on round-sharp needle therapy combined with massage for prolapse of lumbar intervertebral disk]. Zhongguo Zhen Jiu. 2006;26(OCT):719-23. [pmid: 17117572].
195 Zhou Y, L, Liu Y, et al. [Clinical study on analgesic effect of Huaisanzhen on the nerve root pain due to prolapse of lumbar intervertebral disc]. Zhongguo Zhen Jiu. 2005;25(Jan):31-3. [pmid: 16309152].
196 Li Y, Liu Y. [Therapeutic effect of acupuncture on postoperative recovery of prolapse of lumbar intervertebral disc]. Zhongguo Zhen Jiu. 2006;26(Aug):566-8. [pmid: 16941976].
197 Kwon Y, Lee S, Lee C, et al. The short-term efficacy of acupuncture for chronic low back pain: randomized sham controlled trial. J Orient Rehab Med. 2007;17(2):123-32.
198 Leibing E, Leonhardt U, Koster G, et al. Acupuncture treatment of chronic low-back pain -- a randomized, blinded, placebo-controlled trial with 9-month follow-up. Pain. Mar. 2002;96(1-2):189-96. [pmid: 11932074].
199 Mencke M, Wieden TE, Hoppe M, et al. [Acupuncture of shoulder pain and low back pain. Two prospective double-blind studies]. [German]. Akupunktur. 1988;16(4):204-15.
200 Yeung CK, Leung MC, Chow DH. The use of electro-acupuncture in conjunction with exercise for the treatment of chronic low-back pain. J Altern Complement Med. Aug. 2003;9(4):479-90. [pmid: 14499023].
201 Hollisaz MT. Use of electroacupuncture for treatment of chronic sciatic pain. Internet J Pain Sypmtom Contr Palliat Care. 2006;(1):7p.
202 Kennedy S, Baxter GD, Kerr DP, et al. Acupuncture for acute non-specific low back pain: a pilot randomised non-penetrating sham controlled trial. Complement Ther Med. Jun. 2008;16(3):139-46. [pmid: 18534326].
203 Kerr DP, Walsh DM, Baxter D. Acupuncture in the management of chronic low back pain: a blinded randomized controlled trial. Clin J Pain. Nov. 2003;19(6):364-70. [pmid: 14600536].
204 Ceccherelli F, Gagliardi G, Barbagli P, et al. [Correlation between the number of sessions and therapeutical effect in patients suffering from low back pain treated with acupuncture: a randomized controlled blind study]. [Italian]. Minerva Medica. Aug. 4 Suppl 1. 2003;94:39-44. [pmid: 15108610].
205 Ceccherelli F, Rigoni MT, Gagliardi G, et al. Comparison of superficial and deep acupuncture in the treatment of lumbar myofascial pain: a double-blind randomized controlled study. Clin J Pain. May. 2002;18(3):149-53. [pmid: 12048416].
206 Inoue M, Kitakoji H, Ishizaki N, et al. Relief of low back pain immediately after acupuncture treatment--a randomised, placebo controlled trial. Acupunct Med. Sep. 2006;24(3):103-8. [pmid: 17013356].
207 Itoh K, Katsumi Y, Hirota S, et al. Effects of trigger point acupuncture on chronic low back pain in elderly patients--a sham-controlled randomised trial. Acupunct Med. Mar. 2006;24(1):5-12. [pmid: 16618043].
208 Itoh K, Katsumi Y, Kitakoji H. Trigger point acupuncture treatment of chronic low back pain in elderly patients--a blinded RCT. Acupunct Med. Dec. 2004;22(4):170-7. [pmid: 15628774].
209 Sakai T, Tsutani K, Tsukayama H, et al. Multi-center randomized controlled trial of acupuncture with electric stimulation and acupuncture-like transcutaneous electricial nerve stimulation for lumbago. J Japan Soc Acupunct Moxibustion. 2001;51:175-84.
210 Inoue M, Ktakouji H, Ikeuchi R, et al. [Randomized controlled pilot study comparing manual acupuncture with sham acupuncture for lumbago (2nd report)]. J Japan Soc Acupunct Moxibustion. 2001;51(3):412.
211 Takeda H, Nabeta T. [Randomized controlled trial comparing the effect of distal pint needling with local point needling for low back pain]. J Japan Soc Acupunct Moxibustion. 2001;51(3):411.
212 Araki S, Kawamura O, Mataka T, et al. [Randomized controlled trial comparing the effect of manual acupuncture with sham acupunture ofr acute low back pain]. J Japan Soc Acupunct Moxibustion. 2001;51(3):382.
213 Inoue M, Ktakouji H, Ikeuchi R, et al. [Randomized controlled pilot study comparing acupuncture with sham acupunture for lumbago]. J Japan Soc Acupunct Moxibustion. 2000;50(2):356.
214 Sakai T, Tsukayama H, Amagai H, et al. [Controlled trial on acupuncture for lumbago]. J Japan Soc Acupunct Moxibustion. 1998;48(1):110.
215 Kurosu Y. Acupuncture and moxibustion for lumbago (II) - Compartative experiment of the therapeutic effectiveness of acupuncture and garlic moxibustion. J Japan Soc Acupunct Moxibustion. 1979;28(2):31-4.
216 Itoh K, Itoh S, Katsumi Y, et al. A pilot study on using acupuncture and transcutaneous electrical nerve stimulation to treat chronic non-specific low back pain. Complement Ther Clin Pract. Feb. 2009;15(1):22-5. [pmid: 19161950].
217 Hirota S, Itoh K, Katsumi Y. A controlled clinical trial comparing trigger point acupuncture with tender point acupuncture treatments for chronic low back pain: A pilot study on 9 elderly patients. J Japan Soc Acupunct Moxibustion. 2006;(56):67-85.
218 Kawase Y, Ishigami T, Nakamura H, et al. Acupuncture treatment for lower back pain: Multi-center randomized controlled trial using sham acupuncture as a control. J Japan Soc Acupunct Moxibustion. 2006;(56):140-149.
219 Lee J-W, Kim D-I. A randomized controlled trial to verify effects of Kuesu Point on low back pain and accompanied sciatica. Korean J Oriental Med. 2007;28(4):86-94.
220 Kittang G, Melvaer T, Baerheim A. [Acupuncture contra antiphlogistics in acute lumbago]. [see comment]. [Norwegian]. Tidsskrift for Den Norske Laegeforening. Apr. 20. 2001;121(10):1207-10. [pmid: 11402745].
221 Wang B-X, La J-L. Therapeutic effects of electro-acupuncture and diclofenic on herniation of lumbar intervertebral disc. Chinese J Clin Rehab. 2004;8(17):3413-5.
222 Thomas M, Lundberg T. Importance of modes of acupuncture in the treatment of chronic nociceptive low back pain. Acta Anaesthesiol Scand. Jan. 1994;38(1):63-9. [pmid: 8140876].
223 Macdonald AJ, Macrae KD, Master BR, et al. Superficial acupuncture in the relief of chronic low back pain. Ann R Coll Surg Engl. Jan. 1983;65(1):44-6. [pmid: 6218776].
224 Eisenberg DM, Post DE, Davis RB, et al. Addition of choice of complementary therapies to usual care for acute low back pain: a randomized controlled trial. [see comment]. Spine. Jan. 15. 2007;32(2):151-8. [pmid: 17224808].
225 Chu J, Yuen KF, Wang BH, et al. Electrical twitch-obtaining intramuscular stimulation in lower back pain: a pilot study. [see comment]. Am J Phys Med Rehabil. Feb. 2004;83(2):104-11. [pmid: 14758296].
226 Meng CF, Wang D, Ngeow J, et al. Acupuncture for chronic low back pain in older patients: a randomized, controlled trial. Rheumatology. Dec. 2003;42(12):1508-17. [pmid: 12890859].
227 Coan RM, Wong G, Ku SL, et al. The acupuncture treatment of low back pain: a randomized controlled study. Am J Chinese Med. 1980;8(1-2):181-9.
228 Cherkin DC, Sherman KJ, Avins AL, et al. A randomized trial comparing acupuncture, simulated acupuncture, and usual care for chronic low back pain. Arch Intern Med. May. 11. 2009;169(9):858-66. [pmid: 19433697].
229 Zhang HL. [A randomized controlled trial of electroacupuncture and traction for treatment of nerve-root type cervical spondylosis][Chinese]. Chinese Acupunct Moxibustion. 2003;23(11):637-9.
230 Mathews W, Morkel M, Mathews J. Manipulation and traction for lumbago and sciatica: Physiotherapeutic techniques used in two controlled trials. Physiother Pract. 1988;4(4):201-6.
231 Laim A, Jaggy A, Forterre F, et al. Effects of adjunct electroacupuncture on severity of postoperative pain in dogs undergoing hemilaminectomy because of acute thoracolumbar intervertebral disk disease. J Am Vet Med Assoc. May. 1. 2009;234(9):1141-6. [pmid: 19405884].
232 Zhang D-W, Liang X-F, Wang Q-J. [Clinical research on the treatment of lumbar intervertebral disc protrusion by the combination of acupuncture and massage]. Shanghai J Acupunct Moxibustion. 2002;21(2):22.
233 Kelly DD, Murphy BA, Backhouse DP. Use of a mental rotation reaction-time paradigm to measure the effects of upper cervical adjustments on cortical processing: a pilot study. J Manipulative Physiol Ther. May. 2000;23(4):246-51. [pmid: 10820297].
234 Zhu XM, Polus B. A controlled trial on acupuncture for chronic neck pain. Am J Chinese Med. 2002;30(1):13-28.
235 Sator-Katzenschlager SM, Szeles JC, Scharbert G, et al. Electrical stimulation of auricular acupuncture points is more effective than conventional manual auricular acupuncture in chronic cervical pain: a pilot study. Anesth Analg. Nov. 2003;97(5):1469-73. [pmid: 14570667].
236 Wang XL. [Observation on therapeutic effect of shu-needling therapy as main on cervical spondylosis of nerve root type]. [Chinese]. Zhongguo Zhen Jiu. Jul. 2008;28(7):497-8. [pmid: 18678161].
237 Huang YF, Wang TF, Liu Y, et al. [Clinical observation on Jiquan (HT 1) for treatment of cervical spondylosis of nerve root type]. [Chinese]. Zhongguo Zhen Jiu. Jun. 2008;28(6):427-8. [pmid: 18630541].
238 Jia CS, Shi J, Ma XS, et al. [Comparison of the analgesic effect of acupuncture between otopoint-penetrative needling and otopoint-straight needling for cervical type and nerve-root type cervicospondylopathy]. [Chinese]. Chen Tzu Yen Chiu. 2007;32(3):186-9. [pmid: 17691577].
239 Wang XL, Huang HY. [Observation on therapeutic effect of long-time needle retention at Baihui (GV 20) on vertebroarterial cervical spondylopathy]. [Chinese]. Zhongguo Zhen Jiu. Jun. 2007;27(6):415-6. [pmid: 17663103].
240 Fu ZH, Wang JH, Sun JH, et al. Fu’s subcutaneous needling: possible clinical evidence of the subcutaneous connective tissue in acupuncture. J Altern Complement Med. Jan. 2007;13(1):47-51. [pmid: 17309377].
241 Lu YX, Shan QH. [Clinical observation on treatment of cervicogenic headache with turtle-probing needling at Tianzhu (BL 10)]. [Chinese]. Zhongguo Zhen Jiu. Nov. 2006;26(11):796-8. [pmid: 17165503].
242 Zhu HZ, Quan WC, Zhang XF, et al. [Evaluation on clinical therapeutic effect of needle-knife therapy on cervical spondylosis]. [Chinese]. Zhongguo Zhen Jiu. May. 2006;26(5):316-8. [pmid: 16739840].
243 Bin X, Ling F, Lingxiang H. Clinical observation on cervical spondylopathy of the vertebroarterial type treated by electro-acupuncture. J Tradit Chin Med. 2007;27(1):39-42. [pmid: 17393625].
244 Li D-J, Wang J, Gao Q, et al. Interventional effects of cervical local-point traction manipulation plus silver needle heat conductive treatment for cervical spinal canal stenosis. [Chinese]. Chinese J Clin Rehab. 2006;10(43):7-10.
245 Zhuang L-X, Zhu F-P. [Effect of pressed acupuncture at baihui acupoint on thromboxane A^2^ and prostacyclin in treating vertebral artery type of cervical spondylosis]. [Chinese]. Chinese J Clin Rehab. 2004;8(30):6672-3.
246 Lin M-N, Liu X-X, Liu J-H, et al. Needle scalpel combined with massage therapy and simple massage therapy for nerve-root type cervical spondylopathy: A randomized controlled analysis on 100 patients. Chinese J Clin Rehab. 2004;8(23):4920-1.
247 Zhang W, Zheng J, Zhao X. Treatment of arterial-type cervical spondylosis with acupoint-injection, combined with massage manipulation. Int J Clin Acupunct. 2005;14(4):261-5.
248 Liang ZH, Yang YH, Yu P, et al. [Logistic regression analysis on therapeutic effect of acupuncture on neck pain caused by cervical spondylosis and factors influencing therapeutic effect]. Zhongguo Zhen Jiu. Mar. 2009;29(3):173-6. [pmid: 19358495].
249 Fu WB, Zhang HL, Fan L. [Treatment of cervical spondylopathy by needle pricking: A clinical observation of 56 cases] [Chinese]. New J Tradit Chinese Med. 2005;37(4):65-6.
250 Zeng L. [Treatment of cervical spondylopathy by point-through-point Acupuncture] [Chinese]. Shanghai J Acupunct Moxibustion. 2005;24(7):9-10.
251 Zhao ZY, Cai D, Liang F. [Observation on therapeutic effect of Shencongding moxibustion on cervical headache] [Chinese]. Chinese Acupunct Moxibustion. 2004;24(6):389-91.
252 Li XH. [Therapeutic effect of centro-square needling Dazhui (GV 14) on cervical spondylosis] [Chinese]. Chinese Acupunct Moxibustion. 2004;24(7):455-6.
253 Shang X, Meng X, Dong H, et al. [Clinical observations on the treatment of nerve-root cervical spondylopathy by the combination of adjacent and remote acupoints] [Chinese]. Shanghai J Acupunct Moxibustion. 2002;21(6):12-3.
254 Yang T, Sun F, Zhou YL. [Clinical observation on acupoint sticking therapy for treatment of chronic pain of cervical intervertebral disc]. Zhongguo Zhen Jiu. Mar. 2009;29(3):197-9. [pmid: 19358501].
255 Ceccherelli F, Tortora P, Nassimbeni C, et al. The therapeutic efficacy of somatic acupuncture is not increased by auriculotherapy: a randomised, blind control study in cervical myofascial pain. Complement Ther Med. Mar. 2006;14(1):47-52. [pmid: 16473753].
256 Itoh K, Katsumi Y, Hirota S, et al. Randomised trial of trigger point acupuncture compared with other acupuncture for treatment of chronic neck pain. Complement Ther Med. Sep. 2007;15(3):172-9. [pmid: 17709062].
257 Nabeta T, Kawakita K. Relief of chronic neck and shoulder pain by manual acupuncture to tender points--a sham-controlled randomized trial. Complement Ther Med. Dec. 2002;10(4):217-22. [pmid: 12594972].
258 Petrie JP, Langley GB. Acupuncture in the treatment of chronic cervical pain. A pilot study. Clin Exp Rheumatol. Oct. 1983;1(4):333-6. [pmid: 6335859].
259 Vas J, Perea-Milla E, Mendez C, et al. Efficacy and safety of acupuncture for chronic uncomplicated neck pain: a randomised controlled study. Pain. Dec. 15. 2006;126(1-3):245-55. [pmid: 16934402].
260 Thomas M, Eriksson SV, Lundeberg T. A comparative study of diazepam and acupuncture in patients with osteoarthritis pain: a placebo controlled study. Am J Chinese Med. 1991;19(2):95-100.
261 Lundeberg T, Eriksson SV, Lundeberg S, et al. Effect of acupuncture and naloxone in patients with osteoarthritis pain. A sham acupuncture controlled study. Pain Clinic. 1991;4(3):155-61.
262 Wang C, Xiong Z, Deng C, et al. Miniscalpel-needle versus triggerpoint injection for cervical myofascial pain syndrome: a randomized comparative trial. [see comment]. J Altern Complement Med. Jan. 2007;13(1):14-6. [pmid: 17309371].
263 Ilbuldu E, Cakmak A, Disci R, et al. Comparison of laser, dry needling, and placebo laser treatments in myofascial pain syndrome. Photomed Laser Surg. Aug. 2004;22(4):306-11. [pmid: 15345173].
264 Edwards J, Knowles N. Superficial dry needling and active stretching in the treatment of myofascial pain--a randomised controlled trial. Acupunct Med. Sep. 2003;21(3):80-6. [pmid: 14620302].
265 David J, Modi S, Aluko AA, et al. Chronic neck pain: a comparison of acupuncture treatment and physiotherapy. Br J Rheumatol. Oct. 1998;37(10):1118-22. [pmid: 9825752].
266 Petrie JP, Hazleman BL. A controlled study of acupuncture in neck pain. Br J Rheumatol. Aug. 1986;25(3):271-5. [pmid: 3524727].
267 Salter GC, Roman M, Bland MJ, et al. Acupuncture for chronic neck pain: a pilot for a randomised controlled trial. BMC Musculoskelet Disord. 2006;7:99. [pmid: 17156464].
268 Birch S, Jamison RN. Controlled trial of Japanese acupuncture for chronic myofascial neck pain: assessment of specific and nonspecific effects of treatment. Clin J Pain. Sep. 1998;14(3):248-55. [pmid: 9758075].
269 Chu J. Does EMG (dry needling) reduce myofascial pain symptoms due to cervical nerve root irritation?. Electroencephalogr Clin Neurophysiol. Aug. 1997;37(5):259-72.
270 Coan RM, Wong G, Coan PL. The acupuncture treatment of neck pain: a randomized controlled study. Am J Chinese Med. 1981;9(4):326-32.
271 White PF, Craig WF, Vakharia AS, et al. Percutaneous neuromodulation therapy: Does the location of electrical stimulation effect the acute analgesic response?. Anesth Analg. 2000;91(4):949-54. [pmid: 11004055].
272 Abernethy AP. Randomized controlled trial of acupuncture for chronic neck pain. J Pain Palliat Care Pharmacother. 2008;(2):145-6. [pmid: 19042839].
273 Ernst E, White AR. Acupuncture for back pain: a meta-analysis of randomized controlled trials. Arch Intern Med. Nov. 9. 1998;158(20):2235-41. [pmid: 9818803].
274 Morton JE. Manipulation in the treatment of acute low back pain. J Man Manip Ther. 1999;7(4):182-9.
275 Zhang WB, Cao Y, Sun YA, et al. [Manipulative reduction for lumbar intervertebral disc herniation: a controlled clinical trial]. [Chinese]. Zhongguo Gushang. Apr. 2008;21(4):273-5. [pmid: 19102187].
276 Rasmussen J, Laetgaard J, Lindecrona AL, et al. Manipulation does not add to the effect of extension exercises in chronic low-back pain (LBP). A randomized, controlled, double blind study. Joint Bone Spine. Dec. 2008;75(6):708-13. [pmid: 19028434].
277 Postacchini F, Facchini M, Palieri P. Efficacy of various forms of conservative treatment in low back pain. Neuro-Orthopedics. 1988;(6):28-35.
278 Cherkin DC, Deyo RA, Battie M, et al. A comparison of physical therapy, chiropractic manipulation, and provision of an educational booklet for the treatment of patients with low back pain. [see comment]. N Eng J Med. Oct. 8. 1998;339(15):1021-9.
279 Cote P, Mior SA, Vernon H. The short-term effect of a spinal manipulation on pain/pressure threshold in patients with chronic mechanical low back pain. J Manipulative Physiol Ther. Jul. 1994;17(6):364-8. [pmid: 7964196].
280 Herzog W, Conway PJ, Willcox BJ. Effects of different treatment modalities on gait symmetry and clinical measures for sacroiliac joint patients. J Manipulative Physiol Ther. Feb. 1991;14(2):104-9. [pmid: 1826920].
281 Lalanne K, Lafond D, Descarreaux M. Modulation of the flexion-relaxation response by spinal manipulative therapy: a control group study. J Manipulative Physiol Ther. Mar. 2009;32(3):203-9. [pmid: 19362230].
282 Dai D, Fang M, Shen G. A study on lumbar stability of degenerative spondylolisthesis treated with spine fine adjusting manipulation. [Chinese]. Chinese J of Rehab Med. 2006;21(12):1110-2.
283 Bronfort G. Chiropractic versus general medical treatment of low back pain: a small scale controlled clinical trial. Am J Chiropractic Med. Dec. 1989;2(4):145-50.
284 Rasmussen GG. Manipulation in treatment of low back pain (a randomized clinical trial). Manual Med. 1979;17(1):8-10.
285 Shearar K, A, Colloca C, et al. A randomized clinical trial of the relative effectiveness of manual versus mechanical force chiropractic adjustments in the management of sacroiliac joint syndrome. J Chiropr Edu. 2004;18(SPR):29.
286 Mohseni-Bandpei MA, Critchley J, Staunton T, et al. A prospective randomised controlled trial of spinal manipulation and ultrasound in the treatment of chronic low back pain. Physiotherapy. 2006;92(1):34-42.
287 Shah M. Study to evaluate outcome of acute backache with drug therapy and manipulation. Manual Med. 1989;4(3):99.
288 Evans DP, Burke MS, Lloyd KN, et al. Lumbar spinal manipulation on trial. Part I--clinical assessment. Rheumatol Rehabil. Feb. 1978;17(1):46-53. [pmid: 153574].
289 Haas M, Groupp E, Kraemer DF. Dose-response for chiropractic care of chronic low back pain. Spine J. Sep. 2004;4(5):574-83. [pmid: 15363431].
290 Hsieh CY, Adams AH, Tobis J, et al. Effectiveness of four conservative treatments for subacute low back pain: a randomized clinical trial. Spine. Jun. 1. 2002;27(11):1142-8. [pmid: 12045509].
291 Sanders GE, Reinert O, Tepe R, et al. Chiropractic adjustive manipulation on subjects with acute low back pain: visual analog pain scores and plasma beta-endorphin levels. J Manipulative Physiol Ther. Sep. 1990;13(7):391-5. [pmid: 2145384].
292 Buerger AA. A controlled trial of rotational manipulation in low back pain. Manuelle Medizin. 1980;18(2):17-26.
293 Waagen GN, Haldeman S, Cook G, et al. Short term trial of chiropractic adjustments for the relief of chronic low back pain. Manual Med. 1986;2:63-7.
294 Hoiriis K. A clinical trial comparing upper cervical and full spine chiropractic care for chronic low back pain. J Chiropr Educ. 1999;13(1):67-8.
295 Hoehler FK, Tobis JS, Buerger AA. Spinal manipulation for low back pain. JAMA. May. 8. 1981;245(18):1835-8. [pmid: 6453240].
296 Hondras MA, Long CR, Cao Y, et al. A randomized controlled trial comparing 2 types of spinal manipulation and minimal conservative medical care for adults 55 years and older with subacute or chronic low back pain. J Manipulative Physiol Ther. Jun. 2009;32(5):330-43. [pmid: 19539115].
297 Beyerman KL, Palmerino MB, Zohn LE, et al. Efficacy of treating low back pain and dysfunction secondary to osteoarthritis: chiropractic care compared with moist heat alone. J Manipulative Physiol Ther. Feb. 2006;29(2):107-14. [pmid: 16461169].
298 Wilkey A, Gregory M, Byfield D, et al. A comparison between chiropractic management and pain clinic management for chronic low-back pain in a national health service outpatient clinic. J Altern Complement Med. 2008;14(5):465-73. [pmid: 18564952].
299 Aure OF, Nilsen JH, Vasseljen O. Manual therapy and exercise therapy in patients with chronic low back pain: a randomized, controlled trial with 1-year follow-up. [see comment]. Spine. Mar. 15. 2003;28(6):525-31. [pmid: 12642755].
300 Hurley DA, McDonough SM, Dempster M, et al. A randomized clinical trial of manipulative therapy and interferential therapy for acute low back pain. Spine. Oct. 15. 2004;29(20):2207-16. [pmid: 15480130].
301 Farrell JP, Twomey LT. Acute low back pain. Comparison of two conservative treatment approaches. Med J Aust. Feb. 20. 1982;1(4):160-4. [pmid: 6210835].
302 MacDonald RS, Bell CMJ. An open controlled assessment of osteopathic manipulation in nonspecific low-back pain. Spine. 1990;15(5):364-70. [pmid: 2141951].
303 Hawk C, Azad A, Phongphua C, et al. Preliminary study of the effects of a placebo chiropractic treatment with sham adjustments. [see comment]. J Manipulative Physiol Ther. Sep. 1999;22(7):436-43. [pmid: 10519559].
304 Hawk C, Long CR, Rowell RM, et al. A randomized trial investigating a chiropractic manual placebo: a novel design using standardized forces in the delivery of active and control treatments. J Altern Complement Med. Feb. 2005;11(1):109-17. [pmid: 15750369].
305 Cambron JA, Gudavalli MR, Hedeker D, et al. One-year follow-up of a randomized clinical trial comparing flexion distraction with an exercise program for chronic low-back pain. J Altern Complement Med. Sep. 2006;12(7):659-68. [pmid: 16970536].
306 Cleland JA, Glynn P, Whitman JM, et al. Short-term effects of thrust versus nonthrust mobilization/manipulation directed at the thoracic spine in patients with neck pain: a randomized clinical trial. Phys Ther. Apr. 2007;87(4):431-40. [pmid: 17341509].
307 van Schalkwyk R, Parkin-Smith GF. A clinical trial investigating the possible effect of the supine cervical rotatory manipulation and the supine lateral break manipulation in the treatment of mechanical neck pain: a pilot study. [see comment]. J Manipulative Physiol Ther. Jun. 2000;23(5):324-31. [pmid: 10863252].
308 Buchmann J, Wende K, Kundt G, et al. Manual treatment effects to the upper cervical apophysial joints before, during, and after endotracheal anesthesia: A placebo-controlled comparison. Am J Phys Med Rehabil. 2005;84(4):251-7. [pmid: 15785257].
309 Cassidy JD, Lopes AA, Yong-Hing K. The immediate effect of manipulation versus mobilization on pain and range of motion in the cervical spine: a randomized controlled trial. [see comment]. J Manipulative Physiol Ther. Nov. 1992;15(9):570-5. [pmid: 1469341].
310 Martinez-Segura R, Fernandez-de-Las-Penas C, Ruiz-Saez M, et al. Immediate effects on neck pain and active range of motion after a single cervical high-velocity low-amplitude manipulation in subjects presenting with mechanical neck pain: a randomized controlled trial. J Manipulative Physiol Ther. Sep. 2006;29(7):511-7. [pmid: 16949939].
311 Whittingham W, Nilsson N. Active range of motion in the cervical spine increases after spinal manipulation (toggle recoil). J Manipulative Physiol Ther. Nov. 2001;24(9):552-5. [pmid: 11753327].
312 Vernon HT, Aker P, Burns S, et al. Pressure pain threshold evaluation of the effect of spinal manipulation in the treatment of chronic neck pain: a pilot study. J Manipulative Physiol Ther. Jan. 1990;13(1):13-6. [pmid: 2324655].
313 Metcalfe S, Reese H, Sydenham R. Effect of high-velocity low-amplitude manipulation on cervical spine muscle strength: A randomized clinical trial. J Man Manip Ther. 2006;14(3):152-8.
314 Pikula JR. The effect of spinal manipulative therapy (SMT) on pain reduction and range of motion in patients with acute unilateral neck pain: a pilot study. J Can Chiropract Assoc. Jun. 1999;43(2):111-9.
315 Yurkiw D, Mior S. Comparison of two chiropractic techniques on pain and lateral flexion in neck pain patients: a pilot study. Chiropractic Technique. Nov. 1996;8(4):155-62. (25 ref) 1996;(4):155-62.
316 Chen L, Zhang X-L, Ding H, et al. Comparative study on effects of manipulation treatment and transcutaneous electrical nerve stimulation on patients with cervicogenic headache. [Chinese]. J Chin Integrative Med. 2007;5(4):403-6.
317 Nilsson N, Christensen HW, Hartvigsen J. The effect of spinal manipulation in the treatment of cervicogenic headache. J Manipulative Physiol Ther. Jun. 1997;20(5):326-30. [pmid: 9200048].
318 Parkin-Smith GF, Penter CS. A clinical trial investigating the effect of two manipulative approaches in the treatment of mechanical neck pain: a pilot study. JNMS. 1998;(1):6-16.
319 Cilliers KI, Penter CS. Relative effectiveness of two different approaches to adjust a fixated segment in the treatment of facet syndrome in the cervical spine. JNMS. 1998;(1):1-5.
320 Eqwu MO. Relative therapeutic efficacy of some vertebral mobolization techniques in the management of unilateral cervical spondylosis: a comparitive study. J Phys Ther Sci. 2008;20:103-8.
321 Fernandez-de-Las-Penas C, Fernandez-Carnero J, Fernandez AP, et al. Dorsal manipulation in whiplash injury treatment: A randomized controlled trial. J Whiplash Relat Disord. 2004;3(2):55-72.
322 Gonzalez-Iglesias J, Fernandez-de-Las-Penas C, Cleland JA, et al. Thoracic spine manipulation for the management of patients with neck pain: a randomized clinical trial. J Orthop Sports Phys Ther. Jan. 2009;39(1):20-7. [pmid: 19209478].
323 Strunk RG, Hondras MA. A feasibility study assessing manual therapies to different regions of the spine for patients with subacute or chronic neck pain. J Chiropractic Med. Mar. 2008;7(1):1-8.
324 Krauss J, Creighton D, Ely JD, et al. The immediate effects of upper thoracic translatoric spinal manipulation on cervical pain and range of motion: A randomized clinical trial. J Man Manip Ther. 2008;16(2):93-9. [pmid: 19119394].
325 Cleland J. Immediate effects of throacic spine manipulation in patients with neck pain: A randomized clinical trial. J Man Manip Ther. 2004;(12):162.
326 Cleland JA, Childs JD, McRae M, et al. Immediate effects of thoracic manipulation in patients with neck pain: a randomized clinical trial. [see comment]. Man Ther. May. 2005;10(2):127-35. [pmid: 15922233].
327 Haas M, Groupp E, Panzer D, et al. Efficacy of cervical endplay assessment as an indicator for spinal manipulation. [see comment]. Spine. Jun. 1. 2003;28(11):1091-6. [pmid: 12782973].
328 Haas M, Groupp E, Aickin M, et al. Dose response for chiropractic care of chronic cervicogenic headache and associated neck pain: a randomized pilot study. J Manipulative Physiol Ther. Nov. 2004;27(9):547-53. [pmid: 15614241].
329 Sloop PR, Smith DS, Goldenberg E, et al. Manipulation for chronic neck pain. A double-blind controlled study. Spine. Nov. 1982;7(6):532-5. [pmid: 6762670].
330 Bischoff A, Nurnberger A, Voigt P, et al. Osteopathy alleviates pain in chronic non-specific neck pain: randomized controlled trial. Focus Altern Complement Ther. 2003;8(4):537.
331 Boline PD, Kassak K, Bronfort G, et al. Spinal manipulation vs. amitriptyline for the treatment of chronic tension-type headaches: A randomized clinical trial. J Manipulative Physiol Ther. 1995;18(3):148-54. [pmid: 7790794].
332 Fitz-Ritson D, Filonsky N, Salansky N. Efficacy of low energy laser therapy for extensor neck muscles and sleep pattern improvement after “whiplash” injury. J Manipulative Physiol Ther. 1994;17(4):277-8.
333 Bove G, Nilsson N. Spinal manipulation in the treatment of episodic tension-type headache: A randomized controlled trial. JAMA. 1998;280(18):1576-9. [pmid: 9820258].
334 Jensen OK, Nielsen FF, Vosmar L. An open study comparing manual therapy with the use of cold packs in the treatment of post-traumatic headache. Cephalalgia. Oct. 1990;10(5):241-50. [pmid: 2272094].
335 Schiller L. Effectiveness of spinal manipulative therapy in the treatment of mechanical thoracic spine pain: a pilot randomized clinical trial. [see comment]. J Manipulative Physiol Ther. Jul. 2001;24(6):394-401. [pmid: 11514816].
336 Chiradejnant A, Maher CG, Latimer J, et al. Efficacy of “therapist-selected” versus “randomly selected” mobilisation techniques for the treatment of low back pain: a randomised controlled trial. Aust J Physiother. 2003;49(4):233-41. [pmid: 14632622].
337 Goodsell M, Lee M, Latimer J. Short-term effects of lumbar posteroanterior mobilization in individuals with low-back pain. J Manipulative Physiol Ther. Jun. 2000;23(5):332-42. [pmid: 10863253].
338 Chiradejnant A, Latimer J, Maher CG, et al. Does the choice of spinal level treated during posteroanterior (PA) mobilisation affect treatment outcome?. Physiother Theory Pract. Dec. 2002;18(4):165-74.
339 Aleksiev A. Longitudinal comparative study on the outcome of inpatient treatment of low back pain with manual therapy vs. Physical therapy. J Orthopaedic Med. 1995;17(1):10-4.
340 Li Z-Y, Chen P-Q, Gong L, et al. Analgesic effect on lumbar intervertebral disc protrusion-induced back-leg pain by kneading method of taking the tender point as acupoint. [Chinese]. Chinese J Clin Rehab. 2006;10(23):25-7.
341 Ritvanen T, Zaproudina N, Nissen M, et al. Dynamic surface electromyographic responses in chronic low back pain treated by traditional bone setting and conventional physical therapy. [erratum appears in J Manipulative Physiol Ther. 2007 Jul-Aug;30(6):472]. J Manipulative Physiol Ther. Jan. 2007;30(1):31-7. [pmid: 17224353].
342 Hemmila HM, Keinanen-Kiukaanniemi SM, Levoska S, et al. Long-term effectiveness of bone-setting, light exercise therapy, and physiotherapy for prolonged back pain: a randomized controlled trial. J Manipulative Physiol Ther. Feb. 2002;25(2):99-104. [pmid: 11896377].
343 Zaproudina N, Hietikko T, Hanninen OO, et al. Effectiveness of traditional bone setting in treating chronic low back pain: a randomised pilot trial. Complement Ther Med. Jan. 2009;17(1):23-8. [pmid: 19114225].
344 Hemmila HM, Keinanen-Kiukaanniemi SM, Levoska S, et al. Does folk medicine work? A randomized clinical trial on patients with prolonged back pain. Arch Phys Med Rehabil. Jun. 1997;78(6):571-7. [pmid: 9196462].
345 Lopez de Celis C, Barra Lopez ME, Villar ME, et al. [Effectiveness of the posteroanterior mobilization in the lumbar raquis with the Kaltenborn wedge in chronic low back pain patients]. [Spanish]. Fisioterapia. Nov-Dec. 2007;29(6):261-9. (30 ref) 2007;(6):261-9.
346 Wreje U, Nordgren B, Aberg H. Treatment of pelvic joint dysfunction in primary care--a controlled study. [erratum appears in Scand J Prim Health Care 1993 Mar;11(1):25]. Scand J Prim Health Care. Dec. 1992;10(4):310-5. [pmid: 1480873].
347 Mackawan S, Eungpinichpong W, Pantumethakul R, et al. Effects of traditional Thai massage versus joint mobilization on substance P and pain perception in patients with non-specific low back pain. J Bodywork Movement Ther. 2007;11(1):9-16.
348 Konstantinou K, Foster N, Rushton A, et al. Flexion mobilizations with movement techniques: the immediate effects on range of movement and pain in subjects with low back pain. J Manipulative Physiol Ther. Mar. 2007;30(3):178-85. [pmid: 17416271].
349 Hanrahan S, Van Lunen BL, Tamburello M, et al. The short-term effects of joint mobilizations on acute mechanical low back dysfunction in collegiate athletes. J Athl Training. 2005;40(2):88-93.
350 Powers CM, Beneck GJ, Kulig K, et al. Effects of a single session of posterior-to-anterior spinal mobilization and press-up exercise on pain response and lumbar spine extension in people with nonspecific low back pain. Phys Ther. 2008;88(4):485-93. [pmid: 18258767].
351 Timm KE. A randomized-control study of active and passive treatments for chronic low back pain following L5 laminectomy. J Orthop Sports Phys Ther. 1994;20(6):276-86. [pmid: 7849747].
352 Hemmila HM. Bone setting for prolonged neck pain: a randomized clinical trial. J Manipulative Physiol Ther. Sep. 2005;28(7):508-15. [pmid: 16182025].
353 Zaproudina N, Hanninen OO, Airaksinen O. Effectiveness of traditional bone setting in chronic neck pain: randomized clinical trial. J Manipulative Physiol Ther. Jul. 2007;30(6):432-7. [pmid: 17693333].
354 Coppieters MW, Stappaerts KH, Wouters LL, et al. Aberrant protective force generation during neural provocation testing and the effect of treatment in patients with neurogenic cervicobrachial pain. J Manipulative Physiol Ther. 2003;26(2):99-106. [pmid: 12584508].
355 Sterling M, Jull G, Wright A. Cervical mobilisation: concurrent effects on pain, sympathetic nervous system activity and motor activity. Man Ther. May. 2001;6(2):72-81. [pmid: 11414776].
356 Brodin H. Cervical pain and mobilization. Acta Belgica - Medica Physica. Apr. 1983;6(2):67-72.
357 Kanlayanaphotporn R, Chiradejnant A, Vachalathiti R. The immediate effects of mobilization technique on pain and range of motion in patients presenting with unilateral neck pain: a randomized controlled trial. Arch Phys Med Rehab. Feb. 2009;90(2):187-92.
358 Saiz-Llamosas JR, Fernandez-Perez AM, Fajardo-Rodriguez MF, et al. Changes in neck mobility and pressure pain threshold levels following a cervical myofascial induction technique in pain-free healthy subjects. J Manipulative Physiol Ther. Jun. 2009;32(5):352-7. [pmid: 19539117].
359 Kongsted A, Qerama E, Kasch H, et al. Neck collar, “act-as-usual” or active mobilization for whiplash injury? A randomized parallel-group trial. Spine (Phila Pa 1976). Mar. 15. 2007;32(6):618-26. [pmid: 17413465].
360 Farasyn A, Meeusen R, Nijs J. A pilot randomized placebo-controlled trial of roptrotherapy in patients with subacute non-specific low back pain. J Back Musculoskeletal Rehabil. 2006;19(4):111-7.
361 Preyde M. Effectiveness of massage therapy for subacute low-back pain: a randomized controlled trial. Can Med Assoc J. Jun. 27. 2000;162(13):1815-20. [pmid: 10906914].
362 Zhang J-F, Chen W-H. Curative effect of nonoperative therapy for the lumbar disc herniation. [Chinese]. Chinese J Clin Rehab. 2004;8(11):2006-7.
363 Konrad K, Tatrai T, Hunka A, et al. Controlled trial of balneotherapy in treatment of low back pain. Ann Rhuem Dis. Jun. 1992;51(6):820-2.
364 Hsieh LL, Kuo CH, Lee LH, et al. Treatment of low back pain by acupressure and physical therapy: randomised controlled trial. [see comment]. BMJ. Mar. 25. 2006;332(7543):696-700. [pmid: 16488895].
365 Hsieh LL, Kuo CH, Yen MF, et al. A randomized controlled clinical trial for low back pain treated by acupressure and physical therapy. Prev Med. Jul. 2004;39(1):168-76. [pmid: 15207999].
366 Yip YB, Tse SH. The effectiveness of relaxation acupoint stimulation and acupressure with aromatic lavender essential oil for non-specific low back pain in Hong Kong: a randomised controlled trial. Complement Ther Med. Mar. 2004;12(1):28-37. [pmid: 15130569].
367 Chatchawan U, Thinkhamrop B, Kharmwan S, et al. Effectiveness of traditional Thai massage versus Swedish massage among patients with back pain associated with myofascial trigger points. J Bodywork Movement Ther. 2005;9(4):298-309.
368 Quinn F, Hughes CM, Baxter GD. Reflexology in the management of low back pain: a pilot randomised controlled trial. Complement Ther Med. Feb. 2008;16(1):3-8. [pmid: 18346622].
369 Poole H, Glenn S, Murphy P. A randomised controlled study of reflexology for the management of chronic low back pain. European Journal of Pain. Nov. 2007;11(8):878-87. [pmid: 17459741].
370 Hernandez-Reif M, Field T, Krasnegor J, et al. Lower back pain is reduced and range of motion increased after massage therapy. Int J Neurosci. 2001;106(3-4):131-45. [pmid: 11264915].
371 Geisser ME, Wiggert EA, Haig AJ, et al. A randomized, controlled trial of manual therapy and specific adjuvant exercise for chronic low back pain. Clin J Pain. Nov. 2005;21(6):463-70. [pmid: 16215330].
372 Field T, Hernandez-Reif M, Diego M, et al. Lower back pain and sleep disturbance are reduced following massage therapy. J Bodywork Movement Ther. 2007;11(2):141-5.
373 Rasmussen-Barr E, Nilsson-Wikmar L, Arvidsson I. Stabilizing training compared with manual treatment in sub-acute and chronic low-back pain. Man Ther. Nov. 2003;8(4):233-41. [pmid: 14559046].
374 Melzack R, Vetere P, Finch L. Transcutaneous electrical nerve stimulation for low back pain. A comparison of TENS and massage for pain and range of motion. Phys Ther. Apr. 1983;63(4):489-93. [pmid: 6220415].
375 Zhang Y-Z, Wang X-H, Xing H-Y, et al. Mechanical effects of traction and massage therapy on cervical spondylopathy. Chinese J Clin Rehab. 2005;9(42):159-61.
376 Fernandez-de-Las-Penas C, Alonso-Blanco C, Fernandez-Carnero J, et al. The immediate effect of ischemic compression technique and transverse friction massage on tenderness of active and latent myofascial trigger points: A pilot study. J Bodywork Movement Ther. 2006;10(1):3-9.
377 Meseguer AA, Fernandez-de-Las-Penas C, Navarro-Poza JL, et al. Immediate effects of the strain/counterstrain technique in local pain evoked by tender points in the upper trapezius muscle. Clinical Chiropractic. Sep. 2006;9(3):112-8. (24 ref) 2006;9(3):112-8.
378 Hou CR, Tsai LC, Cheng KF, et al. Immediate effects of various physical therapeutic modalities on cervical myofascial pain and trigger-point sensitivity. Arch Phys Med Rehab. Oct. 2002;83(10):1406-14.
379 Yagci N, Uygur F, Bek N. Comparison of connective tissue massage and spray-and-stretch technique in the treatment of chronic cervical myofascial pain syndrome. Pain Clinic. 2004;16(4):469-74.
380 Gemmell H, Miller P, Nordstrom H. Immediate effect of ischaemic compression and trigger point pressure release on neck pain and upper trapezius trigger points: A randomised, controlled trial. Clinical Chiropractic. Mar. 2008;11(1):30-6.
381 Blikstad A, Gemmell H. Immediate effect of activator trigger point therapy and myofascial band therapy on non-specific neck pain in patients with upper trapezius trigger points compared to sham ultrasound: A randomised controlled trial. Clinical Chiropractic. Mar. 2008;11(1):23-9.
382 Cen SY, Loy SF, Sletten EG, et al. The effect of traditional Chinese Therapeutic Massage on individuals with neck pain. Clin Acupunct Orient Med. 2003;4(2-3):88-93.
383 Sherman KJ, Cherkin DC, Hawkes RJ, et al. Randomized trial of therapeutic massage for chronic neck pain. Clin J Pain. Mar. 2009;25(3):233-8. [pmid: 19333174].
384 Hanten WP, Barrett M, Gillespie-Plesko M, et al. Effects of active head retraction with retraction/extension and occipital release on the pressure pain threshold of cervical and scapular trigger points. Physiother Theory Pract. 1997;13(4):285-91.
385 Niemisto L, Lahtinen-Suopanki T, Rissanen P, et al. A randomized trial of combined manipulation, stabilizing exercises, and physician consultation compared to physician consultation alone for chronic low back pain. Spine. Oct. 1. 2003;28(19):2185-91. [pmid: 14520029].
386 Seferlis T, Lindholm L, Nemeth G. Cost-minimisation analysis of three conservative treatment programmes in 180 patients sick-listed for acute low-back pain. Scand J Prim Health Care. Mar. 2000;18(1):53-7. [pmid: 10811045].
387 Hoving JL, Korthals-de B, I, De VH, et al. The effects and costs of manual therapy, physiotherapy and treatment by the general practitioner in neck disorders: A randomized clinical experiment. [Dutch]. Huisarts en Wetenschap. 2004;47(5):218-26.
388 Seferlis T, Nemeth G, Carlsson AM, et al. Conservative treatment in patients sick-listed for acute low-back pain: a prospective randomised study with 12 months’ follow-up. Eur Spine J. 1998;7(6):461-70. [pmid: 9883955].
389 Thomas KJ, MacPherson H, Ratcliffe J, et al. Longer term clinical and economic benefits of offering acupuncture care to patients with chronic low back pain (Structured abstract). Health Technol Assess. 2005;140.
390 Ernst E, Tillett R, Tveito TH, et al. United Kingdom back pain exercise and manipulation (UK BEAM) trial UK BEAM Trial Team United Kingdom back pain exercise and manipulation (UK BEAM) randomised trial: effectiveness of physical treatments for back pain in primary care. BMJ. 2004;329(11 December):1377-81. BMJ 2005 Mar 19; 330(7492): 673-4 (11 ref) 2005;(7492):673-4. [pmid: 15556955].
391 Santilli V, Beghi E, Finucci S. Chiropractic manipulation in the treatment of acute back pain and sciatica with disc protrusion: a randomized double-blind clinical trial of active and simulated spinal manipulations. Spine J. Mar. 2006;6(2):131-7. [pmid: 16517383].
392 Cook C, Cook A, Worrell T. Manual therapy provided by physical therapists in a hospital-based setting: a retrospective analysis. J Manipulative Physiol Ther. Jun. 2008;31(5):338-43. [pmid: 18558275].
393 Kohlbeck FJ, Haldeman S, Hurwitz EL, et al. Supplemental care with medication-assisted manipulation versus spinal manipulation therapy alone for patients with chronic low back pain. J Manipulative Physiol Ther. May. 2005;28(4):245-52. [pmid: 15883577].
394 Smith WS, Johnston SC, Skalabrin EJ, et al. Spinal manipulative therapy is an independent risk factor for vertebral artery dissection. [see comment]. Neurology. May. 13. 2003;60(9):1424-8. [pmid: 12743225].
395 Cassidy JD, Boyle E, Cote P, et al. Risk of vertebrobasilar stroke and chiropractic care: results of a population-based case-control and case-crossover study. J Manipulative Physiol Ther. Feb. 2 Suppl. 2009;32:S201-S208. [pmid: 19251066].
396 Lundeberg T, Lund I, Sing A, et al. Is Placebo Acupuncture What It is Intended to Be. Evid Based Complement Alternat Med. 2009. Jun. 12.
397 Le BD, Willer JC, De BT. Morphine blocks descending pain inhibitory controls in humans. Pain. Jan. 1992;48(1):13-20. [pmid: 1738569].
398 van Tulder MW, Cherkin DC, Berman B, et al. Acupuncture for low back pain. Cochrane Database Syst Rev. 2000;(2):CD001351. [pmid: 10796434].
399 Yuan J, Purepong N, Kerr DP, et al. Effectiveness of acupuncture for low back pain: a systematic review. [Review] [89 refs]. Spine. Nov. 1. 2008;33(23):E887-E900. [pmid: 18978583].
400 Le BD, Villanueva L, Bouhassira D, et al. Diffuse noxious inhibitory controls (DNIC) in animals and in man. Patol Fiziol Eksp Ter. Jul. 1992;(4):55-65.
401 Fu LM, Li JT, Wu WS. Randomized Controlled Trials of Acupuncture for Neck Pain: Systematic Review and Meta-Analysis. J Altern Complement Med. 2009. Feb. 13.
402 Hurwitz EL, Carragee EJ, van d, V, et al. Treatment of neck pain: noninvasive interventions: results of the Bone and Joint Decade 2000-2010 Task Force on Neck Pain and Its Associated Disorders. J Manipulative Physiol Ther. Feb. 2 Suppl. 2009;32:S141-S175. [pmid: 19251061].
403 Trinh KV, Graham N, Gross AR, et al. Acupuncture for neck disorders. Cochrane Database Syst Rev. 2006;3:CD004870. [pmid: 16856065].
404 Cherkin DC, Deyo RA, Wheeler K, et al. Physician views about treating low back pain. The results of a national survey. Spine. 1995;20(1):1-9. [pmid: 7709266].
405 Kopansky-Giles D, Papadopoulos C. Canadian chiropractic resources databank (CCRD): a profile of Canadian chiropractors. J Can Chiropr Assoc. 1997;41:155-91.
406 Ontario Ministry of Health and Long Term Care. The 1990 Ontario health survey. Ontario Ministry of Health and Long Term Care. 1991.
407 Bouwmeester W, van Enst A, van Tulder M. Quality of low back pain guidelines improved. Spine (Phila Pa 1976). Nov. 1. 2009;34(23):2562-7. [pmid: 19841612].
408 Jette AM, Delitto A. Physical therapy treatment choices for musculoskeletal impairments. Phys Ther. Feb. 1997;77(2):145-54. [pmid: 9037215].
409 Reid D, Larmer P, Robb G, et al. Use of a vignette to investigate the physiotherapy treatment of an acute ankle sprain: Report of a survey of New Zealand physiotherapists. N Z J Physiother. 2002;30(2):36-45.
410 Gross AR, Haines T, Goldsmith CH, et al. Knowledge to action: a challenge for neck pain treatment. J Orthop Sports Phys Ther. May. 2009;39(5):351-63. [pmid: 19521013].
411 MacDermid JC, Walton DM, Avery S, et al. Measurement properties of the neck disability index: a systematic review. J Orthop Sports Phys Ther. May. 2009;39(5):400-17. [pmid: 19521015].
412 Stevinson C, Honan W, Cooke B, et al. Neurological complications of cervical spine manipulation. Journal of the Royal Society of Medicine. 2001;94(3):107-10. [pmid: 11285788].
413 Gouveia LO, Castanho P, Ferreira JJ, et al. Chiropractic manipulation: reasons for concern?. Clin Neurol Neurosurg. Dec. 2007;109(10):922-5. [pmid: 17904731].
414 Haldeman S, Carey P, Townsend M, et al. Clinical perceptions of the risk of vertebral artery dissection after cervical manipulation: the effect of referral bias. Spine J. Sep. 2002;2(5):334-42. [pmid: 14589464].
415 Rivett DA, Sharples KJ, Milburn PD. Effect of premanipulative tests on vertebral artery and internal carotid artery blood flow: a pilot study. J Manipulative Physiol Ther. Jul. 1999;22(6):368-75. [pmid: 10478768].
416 Di Fabio RP. Manipulation of the cervical spine: risks and benefits. Phys Ther. Jan. 1999;79(1):50-65. [pmid: 9920191].
417 Ernst E. Manipulation of the cervical spine: a systematic review of case reports of serious adverse events, 1995-2001. Med J Aust. Apr. 15. 2002;176(8):376-80. [pmid: 12041633].
418 Hurwitz EL, Aker PD, Adams AH, et al. Manipulation and mobilization of the cervical spine. A systematic review of the literature. Spine (Phila Pa 1976). Aug. 1. 1996;21(15):1746-59. [pmid: 8855459].
419 Carnes D, Mullinger B, Underwood M. Defining adverse events in manual therapies: A modified Delphi consensus study. Man Ther. 2010;15(1):2-6. [pmid: 19443262].
420 Assendelft W, Morton S, Yu E, et al. Spinal manipulative therapy for low back pain. A meta-analysis of effectiveness relative to other therapies. Ann Intern Med. 2003;138(11):871-81. [pmid: 12779297].
421 Bronfort G, Evans RL, Maiers M, et al. Spinal manipulation, epidural injections, and self-care for sciatica: a pilot study for a randomized clinical trial. J Manipulative Physiol Ther. Oct. 2004;27(8):503-8. [pmid: 15510093].
422 Guzman J, Haldeman S, Carroll LJ, et al. Clinical practice implications of the Bone and Joint Decade 2000-2010 Task Force on Neck Pain and Its Associated Disorders: from concepts and findings to recommendations. Spine (Phila Pa 1976). Feb. 15. 4 Suppl. 2008;33:S199-S213. [pmid: 18204393].
423 Gross A, Miller J, D’Sylva J, et al. Manipulation or mobilization for neck pain. Cochrane Database Syst Rev. 2010;(1).
424 Vernon H, Humphreys K, Hagino C. Chronic mechanical neck pain in adults treated by manual therapy: a systematic review of change scores in randomized clinical trials. J Manipulative Physiol Ther. Mar. 2007;30(3):215-27. [pmid: 17416276].
425 Verhagen AP, Scholten-Peeters GG, van WS, et al. Conservative treatments for whiplash. Cochrane Database Syst Rev. 2007;(2):CD003338. [pmid: 17443525].
426 Hurwitz EL, Carragee EJ, van d, V, et al. Treatment of neck pain: noninvasive interventions: results of the Bone and Joint Decade 2000-2010 Task Force on Neck Pain and Its Associated Disorders. Spine (Phila Pa 1976). Feb. 15. 4 Suppl. 2008;33:S123-S152. [pmid: 18204386].
427 Miller J, Gross A, D’Sylva J, et al. Manual therapy and exercise for neck pain: A systematic review. [In Press]. Man Ther. 2009.
428 D’Sylva J, Miller J, Gross A, et al. Manual therapy with or without physical medicine modalities for neck pain: A systematic review. [In Press]. Man Ther. 2010.
429 Fritz JM, Delitto A, Erhard RE. Comparison of classification-based physical therapy with therapy based on clinical practice guidelines for patients with acute low back pain: a randomized clinical trial. Spine. Jul. 1. 2003;28(13):1363-71. [pmid: 12838091].
430 Brennan GP, Fritz JM, Hunter SJ, et al. Identifying subgroups of patients with acute/subacute “nonspecific” low back pain: Results of a randomized clinical trial. Spine. 2006;31(6):623-31. [pmid: 16540864].
431 Flynn T, Fritz J, Whitman J, et al. A Clinical Prediction Rule for Classifying Patients with Low Back Pain Who Demonstrate Short-Term Improvement With Spinal Manipulation. Spine. 2002;27(DEC):2835-43. [pmid: 12486357].
432 Furlan AD, Imamura M, Dryden T, et al. Massage for low-back pain. Cochrane Database Syst Rev. 2008;(4):CD001929. 2008. [pmid: 18843627].
433 Haraldsson BG, Gross AR, Myers CD, et al. Massage for mechanical neck disorders. Cochrane Database Syst Rev. 2006;(3):CD004871. [pmid: 16856066].
434 Ezzo J, Haraldsson BG, Gross AR, et al. Massage for mechanical neck disorders: a systematic review. Spine (Phila Pa 1976). Feb. 1. 2007;32(3):353-62. [pmid: 17268268].
435 Sherman KJ, Dixon MW, Thompson D, et al. Development of a taxonomy to describe massage treatments for musculoskeletal pain. BMC Complement Altern Med. 2006;6:24. [pmid: 16796753].
436 Moher D, Schulz KF, Altman D. The CONSORT statement: revised recommendations for improving the quality of reports of parallel-group randomized trials. JAMA. Apr. 18. 2001;285(15):1987-91. [pmid: 11308435].
437 Licciardone JC, Russo DP. Blinding protocols, treatment credibility, and expectancy: Methodologic issues in clinical trials of osteopathic manipulative treatment. J Am Osteopath Assoc. 2006;106(8):457-63. [pmid: 16943515].