# Discussion

## Overview

This evidence report summarized, critically appraised, and compared the evidence on clinical benefits, costs, and harms associated with use of complementary and alternative medicine (CAM) and other therapies for the treatment of adults with low back, neck, and thoracic pain. In this report, results from 364 randomized controlled trials (RCTs) and six nonrandomized (one experimental and five observational) studies are summarized and reviewed. In general, the overall strength of the evidence was graded as low to moderate and the majority of it pertained to chronic nonspecific low back pain. Reporting quality across the trials, especially for harms was poor and inconsistent. The study results were often inconsistent probably due to substantial methodological (e.g., length of followup, blinding, design) and/or clinical (e.g., populations, treatments, and outcomes) diversity which limited the extent of comparability, interpretability, and pooling of the data. The therapy provider’s experience, training, and approaches (e.g., deep or superficial massage, choice of trigger points, needling techniques) which differed across the trials may have additionally contributed to disparate results. Only a few studies measured outcomes at long-term post-treatment followup.

## Acupuncture

### Major Findings - Low Back Pain

- For chronic nonspecific back pain, there was moderate grade evidence that acupuncture was better than sham acupuncture in reducing pain intensity, but only immediately after the end of treatment. The degree of clinical importance for the pooled differences in pain intensity observed between acupuncture and placebo was judged as small. Acupuncture did not differ from placebo in improving post-treatment well-being, disability, use of medication, sick leave, and global improvement (grade: low to moderate).
- Acupuncture was significantly better than no treatment or usual care in reducing immediate- or short-term low back pain intensity, disability, and function (grade: moderate). The ROM and well-being were significantly better after acupuncture versus no treatment (grade: moderate). The clinical importance for the pooled differences in pain intensity observed between acupuncture and no treatment was judged as of medium degree.
- The long-term post-treatment disability and utilization of conventional healthcare did not differ between subjects with low back pain receiving acupuncture and usual care (grade: low).
- Acupuncture did not differ from pain medication but was better than physical therapy in reducing immediate-term post-treatment low back pain or disability (grade: low).
- Manipulation was significantly more effective than acupuncture in reducing immediate post-treatment low back pain intensity (grade: low). The pooled differences observed in pain intensity between acupuncture and manipulation was of significant clinical importance.

### Major Findings - Neck Pain

- There was insufficient evidence regarding benefits of acupuncture compared to no treatment in subjects with neck pain.
- For subjects with chronic neck pain, acupuncture was not different from sham-acupuncture, pain medication, mobilization/traction, or laser therapy in reducing pain or disability after the treatment (grade: low).
- Manipulation was significantly better than acupuncture in reducing immediate or short-term post-treatment pain intensity or disability (grade: low).

### General Issues and Harms

The results suggest that acupuncture might be an option for the treatment of acute, subacute, and chronic LBP (specific or nonspecific cause). For chronic nonspecific back pain there is evidence that real acupuncture is no better than sham acupuncture, but better than no treatment or usual care. The benefit of acupuncture was mostly evident immediately or shortly after the end of the treatment and then faded with time. The evidence base for acute, subacute, and mixed duration specific LBP was very sparse and less conclusive.

Trials that applied sham-acupuncture tended to produce negative results (i.e., statistically nonsignificant) compared to trials that applied other types of placebo (e.g., TENS, medication, laser) between acupuncture and placebo groups. These findings agree with others indicating, that indeed, different types of controls used in acupuncture trials may result in different effects. 3,396 The reasons for inconsistent results observed in acupuncture placebo-controlled trials are not readily explained. One explanation is the beneficial effect of sham-acupuncture which rests on the diffuse noxious inhibitory control (DNIC), where neurons in the dorsal horn of the spinal cord are strongly inhibited by the application of a nociceptive stimulus to any part of the body distinct from their excitatory receptive fields.397 Another explanation could be the nonspecific effects of attention and beliefs in a potentially beneficial treatment. The next explanation is that the risk of bias of individual trials may have an influence on the treatment effect. The sensitivity analysis results of this review did not suggest that the pooled effect of acupuncture (compared to placebo) with respect to back pain intensity was strongly influenced by the risk of bias of the trials.

Since only few trials reported any information on harms, it is difficult to adequately compare the event rates across the treatment arms.

### Consistency With Other Systematic Reviews

The evidence base of acupuncture for low-back pain has grown in the last decade. The first Cochrane review on this topic was published in 1999 and included only eleven RCTs.398 The next update was published in 2005 and included 35 RCTs.3 The present report includes 105 RCTs of acupuncture for low back pain and has a wider scope than the previous Cochrane review since additionally, it includes studies in subjects with specific causes of low back pain.

A recently published systematic review of acupuncture for low-back pain (23 trials) showed similar results to the present report.399 The authors concluded that there was strong evidence that acupuncture is no different from sham acupuncture, basing their conclusion on three trials with low risk of bias that showed no difference 22,37,141 and one trial with high risk of bias that showed acupuncture being superior over sham acupuncture. 207 We based our conclusion on 12 placebo-controlled trials in low back pain. There is still a lot of uncertainty regarding the physiological effects of the needles. 22,27,37,37,99,141,156,197,198,203,206,228 One explanation for the beneficial effects of sham acupuncture is the diffuse noxious inhibitory controls (DNIC) where neurons in the dorsal horn of the spinal cord are strongly inhibited when a nociceptive stimulus is applied to any part of the body, distinct from their excitatory receptive fields. 400 Another explanation could be the nonspecific effects of attention and beliefs in a potentially beneficial treatment.

We identified three systematic reviews for neck pain. 401-403 In the most recently published review completed by the Neck Pain Task Force, 402 only ten studies judged to have adequate internal validity were included and assessed. The authors concluded that acupuncture was likely helpful for neck pain not associated with whiplash associated disorders. 402 Another review by Fu and colleagues 401 included only RCTs with neck pain for at least 1 month, using traditional or electro-acupuncture. They excluded trials in subjects with multiple pain sites, with neck pain not being the main symptom, where only different forms of acupuncture were being compared or if neck pain was not the primary outcome. Based on 14 trials, they found that acupuncture was more effective than placebo or sham acupuncture in the treatment of neck pain for short-term pain reduction. In the third review, 403 ten trials of subjects with chronic neck pain were included. They concluded that there was moderate evidence that acupuncture was more effective for pain relief than some types of sham controls, measured immediately post-treatment; there was limited evidence that acupuncture was more effective than massage at short-term followup; for chronic neck disorders with radicular symptoms, there was moderate evidence that acupuncture was more effective than a wait-list control at short-term followup. Although the present review includes a much wider range of trials, it does find similar results to these reviews.

### Clinical Relevance

Furlan et al., showed that improvement in acute LBP with acupuncture was on average 52.0 percent of the VAS (minimum 25.0 percent and maximum 80.0 percent) while improvement for chronic LBP was on average 32.0 percent of the VAS (min -17 percent and max - 62 percent). For people with chronic LBP receiving no treatment, the average improvement was 6.0 percent, and for sham acupuncture it was 23.0 percent (minimum -19.0 percent and maximum 44.0 percent).3 Thus, acupuncture may be beneficial to those suffering from both acute and chronic low back pain. However, how beneficial acupuncture is when compared to standard medical care is not known.

## Manipulation/Mobilization

### Major Findings – Low Back Pain – Manipulation

- In subjects with nonspecific low back pain, manipulation was significantly better than placebo (grade: moderate) or no treatment (grade: low) in reducing pain intensity, but not disability, pain medication intake or ROM immediately or short-term after the treatment.
- Manipulation did not differ from pain medication in improving pain intensity (grade: low). Results for pain intensity or disability were inconsistent regarding manipulation compared to massage or physiotherapy (grade: low)

### Major Findings – Low Back Pain – Mobilization

- In subjects with acute/subacute or chronic low back pain, mobilization was significantly better than no treatment in improving pain intensity and lumbar flexibility immediately and short-term after the treatment (grade: low).
- Mobilization was similar to placebo in reducing specific acute/subacute or nonspecific mixed duration pain or ROM immediately and short term post-treatment (grade: low).
- Mobilization was similar to physiotherapy (a combination of manual treatment and physical modality but not physical modalities alone) in improving ROM for nonspecific chronic or mixed duration pain immediately and short term post-treatment (grade: low).
- Mobilization was better than physiotherapy (a combination of manual treatment and physical modality but not physical modalities alone) in reducing immediate-term post-treatment pain intensity (grade: low). The differences observed in pooled pain intensity between mobilization and physiotherapy was not of significant clinical importance.

### Major Findings – Neck Pain – Manipulation

- Subjects with neck pain benefited more with manipulation than placebo in terms of pain (grade: moderate), disability (grade; low), and neck flexibility (grade; low).

### Major Findings – Neck Pain – Mobilization

- In subjects with neck pain (chronic, mixed duration), mobilization was better than no treatment in reducing pain intensity (grade: low), but not in reducing the intake of pain medication pills or the number of sick leave days immediately or short-term after the treatment (grade: low).
- Mobilization was more effective than placebo in improving acute/subacute neck pain but not in improving chronic neck pain (grade: low). Mobilization was better than physiotherapy or massage in reducing pain intensity and disability in subjects with chronic nonspecific neck pain at intermediate-term after the treatment (grade: low).

### General Issues and Harms

In general, manipulation was shown to be more effective than placebo or no treatment in reducing pain intensity in subjects with back or neck pain. The benefits of manipulation appeared to be mostly limited to a period immediately or in the short-term (2 weeks to 6 months) following the treatment. Results regarding the comparison of manipulation to other treatments (e.g., pain medication, massage, or physiotherapy) in pain reduction were less consistent. The reviewed evidence indicated that mobilization for back or neck pain as associated with greater reductions in pain intensity compared with no treatment. However, the evidence regarding the comparison of mobilization to placebo was less consistent across subjects with low back and neck pain. Mobilization was better than placebo in reducing pain intensity amongst subjects with acute or subacute neck pain, but not amongst those with chronic neck pain. Some evidence indicated that subjects with low back or neck pain benefited from mobilization more than from physiotherapy in improving pain intensity.

There are various methods and techniques of spinal manipulation and mobilization as well skill levels of manual practitioners. In this review, there were several trials of manipulation and mobilization comparing various methods or techniques. However, due to conflicting results, clinical heterogeneity, and low methodological quality (high risk of bias) across the trials, we were unable to determine which method or technique of manipulation or mobilization is more effective and whether the skill level of the practitioners influenced the outcome.

The lack of long term benefits for spinal manipulation/mobilization is not surprising given the recurrent nature of non specific LBP.279,309 It is uncertain whether manipulation/mobilization received during recurrent episodes (as in clinical practice) rather than during a single episode or period would result in long-term benefit including reduced frequency of recurrences.

Low back pain is one of the most common and expensive disorders in developed countries. There is a high variation in the care provided for low back pain, and the optimal approach remains still unknown. 278,404 Spinal manipulation and mobilization are common treatments for low back pain, particularly among chiropractors and low back pain is the most common complaint seen by chiropractors. 405 One third of all patients who seek care for low back pain, see chiropractors, 406 and over 90 percent of chiropractors use spinal manipulation when treating patients. 407 Physiotherapists and osteopaths also use manipulation and mobilization for the treatment of low back pain, but the evidence on the frequency of their use is limited. For physiotherapists, the use of high velocity low amplitude manipulation in patients with acute low back pain varies from 4.0 percent408 to 2.0 percent409 and the use of mobilization is up to 40.0 percent. Previous research has shown that 25.0 percent-40.0 percent of patients with low back pain referred to physiotherapy were positively identified as likely to benefit from spinal manipulation based on a clinical prediction rules. 306

There is a great diversity in the outcome measures used for pain (18 methods or instruments), function/disability (nine methods), global perceived effect (four methods), patient satisfaction (three methods) and quality of life (five methods).410 The Cochrane Collaboration Back Group has published guidelines recommending key outcome measurement categories and related minimal clinically important difference or minimal detectable change. 14 The psychometric properties and usefulness of key condition-specific disability measures are important to adequately interpret findings. For example, the Neck Disability Index has been recently reviewed for establishing clinically meaningful change.411 Although this is one of the most commonly used instruments for neck pain, the minimal clinically important difference (MCID) was shown to be vary across different studies and disorder types ranging from 5/50 to 19/50. There is some evidence that individualized questionnaires like the Patient Specific Disability added to standardized self-report disability measures may enhance our ability to capture change in clinical trials. Future trials may wish to incorporate such instruments as well as specify the rationale for the MCID.

Only few trials evaluating mobilization and/or manipulation provided any information on the absence or presence of harms. The adverse events were not collected in a systematic manner and were poorly reported. Transient increase in low back pain was among the most common adverse events. Moreover, the findings of three case-control studies6,394,395 suggested that younger adults (≥ 45 years) receiving spinal manipulation were at a higher risk of having vertebral artery dissection or vertebrobasilar vascular accident. However, according to a more recent study, 395 this risk was similar to that related to the visiting a primary care physician for treatment of neck pain. Higher level of evidence from RCTs will help to draw more definitive conclusions regarding the risk of vascular events following manual therapies for neck pain.

Previous studies suggested that manual therapy including spinal manipulation or mobilization for low back pain is rarely associated with serious adverse events. 412,413

A number of investigators have made attempts to estimate the risk for serious adverse events in patients with neck pain receiving manipulation therapy, ranging from one in several million,414 to one in 100,000^415^ but these estimations were limited by numerous methodological flaws and challenges. The evidence for serious or catastrophic events is found only in case reports and retrospective case series or surveys from neurologists.416-418 The inherent bias of retrospective reports is the over-reporting of serious adverse events compared to minor and moderate events. While the calculation of risk for the occurrence of catastrophic events such as stroke or death from cervical manipulation is supported by temporal and biologic plausibility arguments, it is plagued by numerous biases such as measurement or selection bias. The risk for catastrophic events in RCTs could not be estimated. Long term cohort trials and the establishment of mandatory national reporting registries by manipulation therapy practitioners, physicians and neurologists can address this safety issue in CAM treatments. Currently, a paucity of reports of adverse events related to mobilization techniques exists and this needs to be corrected.

The lack of accurate incidence rates for adverse events may be attributed to numerous methodological challenges. The most common problems were: a) the lack of consensus on standardized definitions of adverse events, b) inadequate followup (the followup duration should be long enough to detect adverse events, be able to examine the persistence of benefits, and to assess the sustainability of the intervention), c) short-term followup can exaggerate benefits by overlooking any adverse events which may emerge more slowly. The problem is also impeded when typical symptoms evaluated for benefit are also considered as adverse events. For example, pain relief is a desired outcome of benefit, but if pain increases (short term) as a results of a manual therapy intervention, it is not always clear if this is an adverse event (unintended) or the lack of efficacy of the treatment. Adverse events may depend on accumulated dose or time. A framework for defining adverse events specific to manual therapy has been proposed419 but it falls short of providing standardized definitions with regards to severity and thresholds for adversity of common symptoms.

### Consistency With Other Systematic Reviews

The findings in this review are not divergent from previous reviews. For example, Assendelft et al.,420 conducted a systematic review and meta-analysis of 39 RCTs evaluating manipulation and/or mobilization for patients with acute/subacute or chronic low back pain. This review combined manipulation and mobilization trials and excluded studies that did not assess clinically relevant outcomes such as pain, global improvement or functional status. The authors concluded that spinal manipulation (or mobilization) was more effective (both statistically and clinically important differences were found) than sham therapy or ineffective treatments and equally effective when compared to other effective treatments such as general practitioner care, physiotherapy, exercise or back school. These results were consistent regardless of symptom duration or the presence of back-related leg pain. 420 The benefits were found in the short-term for acute low back pain and in the short and long-term for chronic low back pain. The results did not differ when only trials of spinal manipulation alone were included in the analysis.

Bronfort et al., 421 conducted a systematic review on the efficacy of manipulation or mobilization for low back pain and found moderate evidence that manipulation provided more short-term pain relief than mobilization and detuned diathermy, and limited evidence on faster recovery than the commonly used physical therapy treatment. For chronic low back pain, this review found moderate evidence that manipulation had an effect similar to nonsteroidal antiinflammatory drugs. Manipulation/mobilization was effective in the short term when compared with placebo and general practitioner care, and in the long term compared to physical therapy. There was moderate evidence that manipulation was better than physical therapy and home back exercise in both the short- and long-term. In patients with a mix of acute and chronic low back pain, this review found that manipulation/mobilization provided either similar or better pain outcomes in the short and long term compared with placebo, McKenzie therapy, medical care, management by physical therapists, soft tissue treatment or back school.

The findings of this review regarding neck pain are consistent with those of other reviews.422-426 While some differences can be explained by the inclusion criteria and grading of trials between this and other two reviews,422,423 the major results in general are similar. Two additional systematic reviews 427,428 assessed multimodal interventions that included mobilization and manipulation combined with other interventions. The trials included in these reviews were outside the scope of this review.

### Clinical Relevance

It is uncertain what is the optimal frequency and duration of manipulation/mobilization therapy for nonspecific low back pain. In clinical practice, frequency and duration of treatment are usually tailored to the individual needs of the patient. In this review, adult patients classified as having nonspecific low back pain were assumed to be homogeneous in terms of the disease. However, some evidence suggests that there are subgroups of nonspecific LBP patients who are likely to respond differently to various types of intervention. 429,430 A clinical prediction rule with five variables (symptom duration, fear–avoidance beliefs, lumbar hypomobility, hip internal rotation range of motion, and no symptoms distal to the knee), has been recently developed and validated application of which can increase the probability of success with manipulation from 45 percent to 95 percent for subjects with nonspecific low back pain. 31,431 In clinical practice, only some patients with nonspecific low back pain may receive manipulation depending on the clinical presentation.

In our review the intervention was restricted to manipulation alone, mobilization alone, or combination of manipulation and mobilization. This was done to adequately evaluate these specific interventions. However, this may not reflect the realities of clinical practice, where multi-modal approaches are the norm. Combining various forms of manipulation, mobilization, education and exercise that is individualized to the patient is supported from a theoretical and clinical reasoning perspective. Trials that included multi-modal treatment were excluded from this review, and therefore our findings may not be readily applicable to multimodal treatments used in practice including manipulation or mobilization.

This review attempted to answer the question of efficacy: “Can manipulation or mobilization positively affect neck pain?” The included studies may not reflect typical practice in the community of manual therapy. For example, single session or low dose trials with immediate post-treatment followup tend to give positive findings and exaggerate the treatment benefit. There were some trials in this review that were pragmatic and were designed to answer how well manipulation works in practice. 51,140,307,318,320,321,330,332 These trials tended to have larger samples, a longer duration or higher dose of treatment, enroll more heterogeneous populations, and allow the manual therapy interventions to vary as they would in clinical practice. These effectiveness trials are designed to give a broader clinical applicability. Their findings were more conservative and varied relative to the less pragmatic trials.

## Massage

### Major Findings – Low Back Pain

- Massage was superior to placebo or no treatment (grade: low) in reducing pain (grade: moderate) and disability (grade: low) immediately post-treatment only in subjects with acute/subacute but not in subjects with chronic low back pain (grade: low).
- Massage was significantly better than relaxation (clinical importance of difference: medium degree) or physical therapy (clinical importance of difference: large degree) in reducing chronic nonspecific low back pain intensity but not ROM, immediately after the treatment (grade: low to moderate).

### Major Findings – Neck Pain

- Massage was better than no treatment in reducing immediate-term post-treatment pain intensity in subjects with chronic or unknown duration of nonspecific pain (grade: low).
- Massage was better than placebo in reducing neck pain intensity immediately after the treatment in subjects with acute/subacute or unknown duration of nonspecific pain (grade: low). Massage was not different from placebo in improving well-being or ROM in subjects with chronic pain (grade: low).

### General Issues and Harms

When the outcomes of pain and function are examined, it seems that massage had a more consistent impact in pain intensity than on function or ROM for which many trials had conflicting findings. This might be due to psychological factors that contribute to disability which are not addressed by massage therapy.

Typically, massage therapy is delivered differently in many different parts of the world. The variations in practice settings, study populations, severity of the disorder, duration and number of massage sessions, types of placebo (e.g., TENS, massage) and adjuvant modalities might all contribute to different results. In the reviewed trials, practice settings as well as inclusion and exclusion criteria for study populations were often poorly specified. One bias inherent in all trials was that blinding of the patient, care provider, and often outcome assessor was often not achieved and may have led to exaggerated treatment effect estimates. Blinding of the therapist is not possible, therefore, effort is needed to blind the outcome assessor. In most of the reviewed studies, the primary outcome was a “self-reported” outcome such as pain, global perceived effect, disability/function or quality of life, in other words a “subjective” outcome type. Bias may be introduced when blinding of patients and care giver is inadequate. Furthermore, massage trials often used primary outcomes such as single-item pain scales. For such trials, the patient automatically becomes the “outcome assessor” and therefore cannot be blinded. For other multi-item self report tools, such as the Neck Disability Index, the patient may be naïve, may have lower recall of their original rating and may not always be considered to be the “outcome assessor”. Outcomes utilizing performance based findings are needed to balance the inherent bias in reporting self-reported outcome measures.

Information on harms reported in the massage trials was very limited. No serious adverse events were reported. In a few trials, subjects receiving massage experienced transient back/neck soreness.

### Consistency With Other Systematic Reviews

A Cochrane Review of massage for nonspecific low-back pain, updated in 2008, included 13 RCTs.432 All 13 studies were also included in this review. The present review included four more trials. Two of these trials were published after the Cochrane review, 93,368 and two trials in subjects with disc herniation were excluded from the Cochrane review because of the population eligibility criterion. 159,362 The Cochrane review concluded that “massage was superior for pain and function compared with placebo or no treatment on both short and long-term followups. Massage was similar to exercise, and it was superior to joint mobilization, relaxation therapy, physical therapy, acupuncture, and self-care education.

In two reviews of neck pain, 433,434 limited implications for clinical practice were noted. No recommendations could be made due to unclear evidence and the difficulty in comparing very different massage forms. Four different massage therapy approaches, all in trials of very low quality (high risk of bias) and of moderate clinical applicability showed evidence of no benefit in pain relief when compared to different forms of control treatment. The trials within these two reviews included ischemic compression, the use of a J-cane tool, Western massage, and occipital release for typically subacute or chronic neck pain.

### Clinical Relevance

The application of the massage techniques can be very different in research trials relative to how it is applied in clinical practice. A standardized taxonomy is needed for massage and although one has been suggested,435 there is no movement to adopt it within the research community.

## Cost-Effectiveness of CAM Therapies

There was consistent evidence for the cost-effectiveness of acupuncture for back and neck pain relative to usual care or no treatment, but this was based on only three studies. Because the benefits of spinal manipulation were modest or absent in the six trials of spinal manipulation that included economic analyses, there is no compelling evidence for the cost-effectiveness of this treatment for back or neck pain. The only trial that included massage as a treatment found massage more costly and less effective than usual physician care. In summary, because of the small number of economic evaluations, the inconsistent standards of comparison, and the substantial heterogeneity among these studies (different countries with different health care payment systems), it is not possible to reach clear conclusions about the cost-effectiveness of any of these CAM treatments for back or neck pain or to make global application of the findings. These initial studies suggest that spinal manipulation may not be cost-effective and acupuncture is promising. There have not yet been any economic evaluations of a defined massage treatment protocol for back or neck pain.

## Strengths and Limitations of Review

### Strengths

This review identified a large amount of evidence on efficacy and safety of CAM treatments used in the management of back and neck pain. The reviewers used systematic, comprehensive, and independent strategies to minimize the risk of bias in searching, identifying, retrieving, screening, abstracting, and appraising the primary studies. The search strategy, which was not restricted by the language or year of publication, was applied to multiple electronic sources. Furthermore, the references of included studies were hand-searched for potentially eligible reports. Further strength of this review is that results of individual trials regarding primary outcomes were stratified and subgrouped by spine region (e.g., low back, neck), duration of pain (acute, subacute, chronic, mixed, and unknown), and cause of pain (specific or nonspecific). The reviewers were able to pool results of individual trials in series of meta-analyses for all reviewed major treatments (acupuncture, manipulation, mobilization, and massage) within subgroups of populations defined by spine region (low back, neck), duration of pain (acute, subacute, chronic, mixed, and unknown), and length of post-treatment followup for each outcome (immediate, short-term, intermediate-term, and long-term). The reviewers assessed and reported the degree of clinical importance of the observed statistically significant pooled differences in pain intensity between the treatment groups.

This review assessed the extent of publication bias using a visual inspection of the funnel plot and the Egger’s regression-based technique. 16 Although the visual inspection method is not very reliable, it conveys some general idea as to how symmetrical the dispersion of individual trial effect estimates is around more precise effect.8 Note that methodological and clinical heterogeneity across trials may also contribute to funnel plot asymmetry. 15 The funnel plot of acupuncture placebo-controlled trials showed some degree of asymmetry which may have arisen due to publication bias. Publication bias, if present, may have led to overestimation of the treatment effect of acupuncture compared to placebo in reducing pain intensity. We aimed to minimize publication bias by supplementing the comprehensive search strategy with inclusion of grey literature and reports published in non-English journals.

The collected data allowed us to perform a sensitivity analysis which explored the influence of study quality (i.e., risk-of-bias) on the pooled treatment effect (reduction of pain intensity) in trials comparing acupuncture to placebo.

### Limitations

This review is limited by the information provided in the included primary studies. Most of these studies were of high risk of bias. Many trials had small sample size (e.g. pilot, feasibility studies) or used a single treatment session and may have had limited power to detect clinically meaningful differences in the primary outcomes between the study treatment groups. A high proportion of acupuncture trials published in Chinese did not explicitly define the primary binary outcome ‘curative effect,’ the definition of which may have varied across these trials. Study reports did not always provide sufficient quantitative information (e.g., standard deviations, standard errors, mean endpoints) necessary for pooling the results of individual trials. Authors of many trials failed to report statistical test results for between-group differences in outcome measures after the end of treatment. The occurrence of harms was not reported in the majority of trials, making it difficult to draw definitive conclusions regarding absolute or relative safety of the reviewed treatments.

The risk-of-bias graphs indicated that the adequacy of methods for randomization was not clear for at least 40 percent of all trials. It was not clear whether or not the treatment allocation was concealed for more than half of all trials. Study participants’ blinding status was reported more frequently compared to assessors’ blinding status. The baseline distribution of subjects’ characteristics and study participants’ blinding status were better reported than methods of randomization or treatment of allocation. The overall proportion of double blind trials amongst the trials reporting this information was very low (about 10.0 percent). It should be noted that in most situations where physical treatments are applied, effective blinding is very difficult or impossible to achieve. The absence of data for the above-mentioned domains (i.e., randomization methods, treatment allocation concealment, blinding status) limits the extent of valid interpretation of the review results.

There was substantial clinical (e.g., populations, treatments, and outcomes) and methodological (e.g., length of followup, blinding, design) heterogeneity present across included trials which may have led to the disparate results. For example, there were many different treatment modalities used within acupuncture (e.g., dry needling, conventional needling, warming needle, electro-acupuncture, trigger-point acupuncture, laser-acupuncture), spinal manipulation therapy (e.g., manual manipulation, instrument-assisted manipulation), flexion-distraction technique, osteopathy, mobilization, traditional bone-setting techniques, and massage (e.g., acupressure, reflexology) or their combinations with other therapies (e.g., pain medications, physiotherapy, traction, exercise, standard therapy, advice/education) making it very difficult to meaningfully compare and summarize the efficacy and safety parameters of the review. Moreover, the therapy provider’s experience, training, and approaches (e.g., deep or superficial massage, choice of trigger points, needling techniques) which differed across the trials may have additionally impacted the trial results. The observed variability in the experimental interventions was compounded by a wide variety of control (comparison) treatments used across the trials (e.g., physiotherapy, exercise, advice/book, standard therapy, other CAM therapy, placebo, no treatment). For example, some trials used different types of placebo (detuned short-wave diathermy, superficial needling, TENS placebo, sham manipulation, sham acupuncture, sham massage) whose effects may have been different, thereby contributing additional heterogeneity. The above-mentioned clinical diversity limited the extent of statistical pooling of trial results. Some of the pooled analyses revealed unexplained statistical heterogeneity. Therefore, the results of such meta-analyses should be viewed with caution.

Quantitative subgroup analyses exploring the effects of age, gender, race, type of treatment provider, or dose of treatment could not be performed due to lack or insufficient data. For example, the largest meta-analysis in this review included only 10 trials and the remaining smaller meta-analyses included a range of two to four trials. None of the pooled trials included solely subjects from these subgroups of interest. Similarly, the results from several trials that were conducted in subjects of specific age- or gender-based subgroups (e.g., elderly, young adults, men, and women) were not comparable due to different control treatments used, duration of pain, and/or cause of pain in subjects included in these trials.

One more limitation of this review may be the use of a nonweighted system for averaging risk of bias (i.e. high, medium, low) for multiple studies for grading overall strength of evidence.

This review focused on manipulation or mobilization to estimate the efficacy. Results from these studies may not be readily applicable to various combinations of interventions used in today’s practice. However, the assessment of a single intervention is the first step in teasing out which therapeutic item is more effective in reducing pain and improving function.

## Future Research

Stronger efforts are needed to improve the quality of conduct and reporting of primary studies evaluating CAM therapies. The primary study authors should consider CONSORT statement as a reporting guide in order to improve the quality of reporting. 436 For example, authors of future trials should direct more attention to minimizing bias (e.g., randomization sequence generation, treatment allocation concealment, blinding, incomplete outcome data, and selective outcome reporting) in conducting, analyzing, and reporting results of primary trials.

Some factors that may influence results of clinical trials assessing patient-reported outcomes for manipulative treatments were discussed by Licciardone et al.,437 who listed the following sources of bias: a) attrition or selection bias (e.g., differential dropout or withdrawal rates, self-selection bias), b) investigator bias (e.g., allocation concealment), and c) nonspecific treatment effects due to investigator-subject relationship, regression to the mean, and subjects’ expectation of outcomes/treatment credibility due to awareness of the treatment they are assigned to receive.

Moreover, trial authors need to characterize and report frequency (e.g., number of sessions per unit of time) and duration of treatments used, in order to help establish which of these characteristics make these therapies most optimal in terms of benefits and harms.

Trial investigators need to consider the use of validated instruments for measuring outcomes. Currently, there is a great diversity in outcome measures used for pain, function/disability, global perceived effect, patient satisfaction and quality of life. The Cochrane Collaboration Back Group has published guidelines recommending key outcome measurement categories and related minimal clinically important difference or minimal detectable change. 14 For efficiency purposes, a single trial should ideally measure maximum number of relevant outcomes (pain, function, return to work, and health care utilization). To minimize the risk of bias inherent to some subjective outcome measures (e.g., pain, disability, quality of life, GPE, patient satisfaction), investigators should additionally measure and report objective outcomes (e.g., performance-based outcomes, impairment measures, range of motion, muscle strength).

Since in most studies of low back and neck pain, the primary outcome is self-reported pain, global perceived effect, disability/function or quality of life, the lack of blinding or inadequate blinding of study subjects or outcome assessors may bias the trial results. Therefore, it is important that more efforts be directed towards better blinding methodologies applied in future trials.

For a given trial, it is important to consider an appropriate placebo treatment. For example, in this review, trials that applied sham-acupuncture or sham-manipulation tended to have negative results compared to trials that applied other types of placebo (e.g., no treatment, laser-placebo, TENS-placebo). Future head-to-head trials comparing CAM treatments should ideally have a large sample size, since in case of small trials, it is difficult to explain whether the negative results are due to true equivalence between the interventions or due to small samples.

Factorial design including randomization first to CAM therapy or no treatment, and then randomizing to other treatment modalities would be most informative to delineate the additive/subtractive and individual effects of CAM therapies relative to any given treatment.

Future trials should help to better inform the influence of treatment-, care-provider (e.g. experience, skills), and population-specific factors on treatment effect estimates. It is desirable that treatment providers (chiropractors, acupuncturists, massage therapists) employed in future trials be highly experienced. More research should be conducted elucidating clinical benefits of different forms of CAM therapies relative to each other, since at present there is no clear advantage of any particular type. It is also important to collect and report information on patients’ previous experience, beliefs, and their expectations of CAM therapies to assess the impact of these factors on the success of care. More data from well-conducted trials are needed for definitive conclusions regarding the relationships between the use of CAM and conventional therapies in subjects with neck and back pain.

Finally, the exploration and explanation of key causal or biological mechanisms underlying the effects of CAM therapies and their variation across subgroups of patients are also warranted.