# Results

## Literature Search Results

The original (Oct. 2008) and updated (Feb. 2010) search of MEDLINE, and all other sources (including expert nominated records) for primary studies yielded 10,505 citations. After removing 3,783 duplicate records, titles and abstracts of 6,756 records were screened. Of these, 1,339 were potentially relevant records. We were able to retrieve full text articles for 1,167 records. The remaining 172 records were not further screened since full texts for them could not be obtained.

In total, 811 records did not meet eligibility criteria applied during the full text screening, and therefore were excluded (Appendix D); thus a total of 356 records were included in this report. Of these 356 records, only 33 were quantitatively analyzed. Figure 2 outlines the study flow process for this review.

Figure 2 PRISMA chart for study retrieval and selection

Figure 2 depicts a PRISMA chart for study retrieval and selection. To the left are three horizontal boxes (from the top down), Title & Abstract screening, Full text screening, and Included Studies. On the top are two boxes, Records Identified through database searching n = 10,505, and Reviewer nominated records n = 34. A dotted line from the right hand box line points to a box on the left, Duplicate records removed n = 3,783. Lines come down from the two top boxes to a box, Records eligible for level I screening n = 6,756. A dotted and wavy line from that box points to a box on the right, Records excluded at level I n = 5,417. A line goes down from the middle box (Records eligible for level I screening) to a box, Records eligible for level II screening n = 1,339. A wavy dotted line points right to a box, Full text not available n = 172. A solid line goes down from the middle box to a box, Full text articles assessed for eligibility n = 1,167. A dotted and wavy line goes right to a box, 811 Full text articles, excluded. - 334 Editorial, review, commentary, letter, news, report or case report - 17 Systematic reviews relevant to topic - 45 Non-comparative observational study that may have reported harms of CAM - 29 Comparative observational study not reporting on harms of CAM - 276 Not a CAM intervention or multimodal intervention - 43 Not a relevant population or cause of pain 42 Reported outcome for more than one region without stratification or irrelevant region - 7 Not an eligible language – - 18 Did not report outcome of interest. Another arrow points down from the middle box to a box, Studies included in the qualitative synthesis n = 356 (including 86 2(unclear superscript) publications) - RCTs reporting on efficacy, harms and/or economic evaluation n = 351 (265 primary trials) - Controlled observational studies reporting on harms; n = 5. Two arrows go down from that box to two below it. The box on the left, Low Back Pain (primary studies: n = 187* + 64 2 (unclear superscript) publications) Acupuncture: n = 105 Manual treatments: Manipulation (and flexion-distraction): n = 39 Mobilization: n = 18 Manipulation + mobilization: n = 10 Massage: n = 20 Economic: n = 7. The right hand box, Neck Pain (primary studies: n = 109* = 27 2 (superscript unclear) publications) Acupuncture: n = 52 Manual treatments: Manipulation: n = 29 Mobilization: n = 12 (+ 1 thoracic study) Manipulation + mobilization: n = 2 Massage: n = 15 Economic: n = 3. From those two boxes, two lines come down to converge on the bottom box, Studies included in quantitative analyses n = 33.

## General Characteristics of the Included Studies

Of the 356 included records, 86 were identified as multiple publications of the primary studies. In this review, multiple publication is defined as a single study results published more than once, or part of data from an original report was republished separately. In general, a publication that provided the most comprehensive report of the original trial was used as the primary study. If multiple publications included the same data, the report published earlier was regarded as the main study.

The publication date of primary studies ranged from 1976 to 2009. The included records were published in English (273), Chinese (72), German (10), Japanese (nine), Spanish (one), and Italian (one) language.

In total, 270 unique studies were included in this report. Table 3 outlines the included original and secondary publications. Of the 270 primary studies, 265 were RCTs and five were cohort or case-control studies.

Table 3 Primary records with companion reports

Primary Record | Secondary record(s)
Aigner 1999^17^ | Aigner 1998^18^; Aigner 1998^19^
Alaksiev 1996^20^ | Alaksiev 1994^21^
Brinkhaus 2006^22^ | Brinkhaus 2003^23^
Witt 2006^24^ | Witt 2005^25^; Witt 2006^26^
Carlsson 2001^27^ | Carlsson 1993^28^
Cherkin 2001^29^ | Kalaukalani 2001^30^
Childs 2004^31^ | Childs 2003^32^; Childs 2006^33^; Fritz 2005^34^; Whitman 2004^35^; Childs 2004^36^
Endres 2007^37^ | Haake 2007^38^
Ferreira 2007^39^ | Ferreira 2009^40^
Franke 2000^41^ | Franke 2000^42^
Fryer 2005^43^ | Hodgson 2006^44^
Ga 2007^45^ | Ga 2007^46^
Gallacchi 1983^47^ | Gallacch 1981^48^
Garvey 1989^49^ | Garvey 1990^50^
Giles 2003^51^ | Muller 2005^52^
Grant 1999^53^ | Grant 1998^54^
Hadler 1987^55^ Hancock 2007^56^ Hoiriss 2004^57^ | Hadler 1990^58^ Hancock 2008^59^;Badgett 2008^60^ Hoiriis 2002^61^
Hoving 2006^62^ | Kothals-de-Bos 2003^63^; Kothals-de-Bos 2005^64^
Hurwitz 2002^65^ Hurwitz 2006^66^ | Hurwitz 2006^67^;Hurwitz 2004^68^;Hurwitz 2005^69^ Hertzman-Miller 2002^70^; Hurwitz 2005^71^; Kominski 2005^72^; Goldstein 2002^73^; Hurwitz 2002^74^; Hurwitz 2002^75^; Hurwitz 2002^76^
Irnich 2001^77^ | Irnich 2000^78^; Konig 2003^79^
Irnich 2002^80^ | Irnich 2002^82^
Jull 2005^81^ | Jull 2002^83^
Koes 1992^84^ Koes 1993^85^ | Koes 1993^85^; Koes 1992^86^ Koes 1992^86^; Koes 1992^87^
Kothals-de-Bos 2003^63^ | Hoving 2006^62^
Lehmann 1983^88^ Lewis 2007^89^ Little 2008^90^ | Lehmann 1986^91^ Dziedzic 2005^92^ Little 2008^93^; Hollinghurst 2008^94^
Meade 1991^95^ | Meade 1995^96^; Meade 1990^97^; Meade 1990^98^
Molsberger 2002^99^ | Molsberger 1998^100^
Pope 1994^101^ | Hsieh 1992^102^; Pope 1993^103^
Rupert 1985^104^ | Rupert 1985^105^
Seidel 2002^106^ | Seidel 2003^107^
Sims-Williams 1979^108^ | Jayson 1981^109^
Thomas 2005^110^ | Thomas 2006^111^; Ratcliffe 2006^112^; Thomas 2009^113^; Thomas 2003^114^; Thorpe 2002^115^; Thorpe 2002^116^; MacPherson 2004^117^; MacPherson 2002^118^
Triano 1995^119^ | Triano 1994^120^
Tsukayama 2002^121^ | Tsukayama 2000^122^
UK BEAM Trial Team 2004^123^ | Farrin 2005^124^; UK BEAM Trial Team 2004^125^
Venancio 2008^126^ | Venancio 2009^127^
White 2004^128^ | White 2002^129^
Willich 2006^130^ | Witt 2006^131^
Witt 2006^131^ | Becker-Witt 2004^132^; Walsh 2005^133^; Willich 2006^130^
Yuan 2006^134^ | Yuan 2004^135^
Yuan 2009^136^ | Yuan 2006^137^
Zhang 2008^138^ | Zhang 2007^139^

The CAM interventions in the 265 RCTs (351 publications) were acupuncture (155 trials), spinal manipulation (66 trials), spinal mobilization (29 trials), spinal manipulation + mobilization (11 trials), and massage (33). There were few studies in which both regions of pain, or more than one CAM interventions were studied. Ten trials of economic evaluation of CAM treatments were also included.

### Assessment of Risk of Bias

RCTs reporting efficacy and harms. The risk of bias was assessed for 242 studies. The remaining RCTs were reported in abstract form and were not suitable for this assessment. Overall, the metrological quality of the RCTs were poor (median score = 5/13; Inter-quartile range: 3, 7). Only 94 (39 percent) of the studies scored six or higher from the total of 13 items of risk of bias tool. We found that 99 (41 percent) studies described an adequate method of randomization. The remaining studies either did not report the method used for randomization (7.0 percent) or the method used was not clearly described (52.0 percent). Concealment of treatment allocation was judged as adequate in 21.1 percent of RCTs and inadequate in 10.3 percent. More information on rating of risk of bias is provided in Table 4 and Appendix G.

Table 4 Risk of bias assessment of RCTs

Quality components | N studies (%)
Adequate method of randomization | 99 (40.9%)
Adequate method of allocation concealment | 51 (21.1%)
Similarity at baseline regarding the most important prognostic indicators | 158 (65.3%)
Appropriate patient blinding to the intervention | 43 (17.8%)
Appropriate care provider blinding to the intervention | 7 (2.9%)
Appropriate outcome assessor blinding to the intervention | 85 (35.1%)
Similar or no cointerventions between groups | 103 (42.6%)
Acceptable compliance in all groups | 82 (33.9%)
Described and acceptable drop-out rates | 132 (54.5%)
Similarity of timing of the outcome assessment in all groups | 214 (88.4%)
Inclusion of an intention-to-treat analysis | 84 (34.7%)
Absence of selective outcome reporting | 127 (52.5%)
Absence of other potential bias | 12 (5.0%)
Total Risk of Bias scores (max 13); median (IQR) | 5 (3, 7)

RCTs reporting economic evaluation. Three studies collected costs appropriate to their chosen perspective. Two studies did not state the perspective adopted for the economic evaluation. Most studies measured costs using diaries, questionnaires, or practice or insurance records, and valued costs appropriately using published sources. Where appropriate, most studies conducted an incremental cost-effectiveness analysis. The length of followup for all of the studies was at least 1 year. In one study whose length of followup was more than 1 year, discounting was undertaken. Appendix G – Tables 5.1 & 5.2 shows the results of the assessment of the quality of the economic evaluations.

Controlled observational studies (cohort, case-control). Assessment of quality of reporting in observational studies was done by using the modified Downs and Black tool. In general, the objective, and the main outcome of the studies were well described and the studies were of large sample size providing sufficient power to detect clinically important effects. Detail information could be found in Appendix G, table 6.1.

Risk of bias of RCTs by CAM intervention. In this review the results are presented for CAM interventions for treatment of low back pain, thoracic pain, and neck pain. For each of these pain regions, the CAM interventions are organized by the following order:

- Acupuncture
- Spinal manipulation
- Flexion distraction technique (only for LBP)
- Spinal mobilization
- Spinal manipulation + mobilization
- Massage

Summary of the results of risk of bias assessment for these CAM interventions within each pain region (LBP, NP) is presented in the respective sections of the results (Figures 3, 24, 27, 28, 29, 30, 31, 42, 43, and 47). Here we attempted to compare the risk of bias in the included studies across the five CAM interventions. The summary of findings regarding the most relevant items of risk of bias are outlined in Table 5. In summary, the items related to randomization, concealment of treatment allocation, differences in baseline prognostic indicators, blinding of outcome assessor, imbalance in use of cointervention, reporting of intention to treat analysis, and selected outcome reporting bias was the focus of this comparison. As judged by median and inter quartile ranges of total score (13 items), trials in manual therapies of LBP had slightly lower risk of bias (median 7, 8, and 6 for spinal mobilization, manipulation + mobilization, and massage, respectively) with the exception of manipulation therapy (median score = 2, IQR 1, 3) compared with acupuncture (median score = 4, IQR 1, 3). In the trials on treatment of neck pain, there was no difference in the total scores (median scores = 4, 3, 3, and 5 for acupuncture, manipulation, mobilization, and massage, respectively).

Table 5 Selected risk of bias tool assessment items in RCTs by CAM treatment type

Selected Items of Risk of Bias tool | Acupuncture | | Spinal manipulation | | Spinal mobilization | | Manipulation+mobilization | Massage
Selected Items of Risk of Bias tool | LBP | NP | LBP | NP | LBP | NP | LBP | LBP | NP
Appropriate method of randomization | 44 (43.1) | 14 (26.4) | 6 (18.2) | 15 (51.7) | 6 (37.5) | 4 (44.4) | 6 (66.7) | 10 (50.0) | 6 (37.5)
Inappropriate method of randomization | 10 (9.8) | 4 (7.5) | 4 (12.1) | 2 (6.9) | 1 (6.3) | 1 (11.1) | 0 | 1 (5.0) | 0
Appropriate concealment of treatment allocation | 20 (19.6) | 8 (15.1) | 3 (9.1) | 10 (34.5) | 3 (18.8) | 5 (55.6) | 4 (44.4) | 4 (20.0) | 3 (18.8)
Inappropriate concealment of treatment allocation | 11 (10.8) | 2 (3.8) | 7 (21.2) | 4 (13.8) | 2 (12.5) | 1 (11.1) | 1 (11.1) | 3 (15.0) | 0
Dissimilarity of baseline prognostic indicators | 8 (7.8) | 6 (11.3) | 3 (9.1) | 4 (13.8) | 1 (6.3) | 0 | 1 (11.0) | 1 (5.0) | 5 (31.3)
Appropriate outcome assessor blinding | 29 (28.4) | 14 (26.4) | 15 (45.5) | 10 (34.5) | 10 (62.5) | 5 (55.6) | 5 (55.6) | 4 (40.0) | 7 (43.8)
Inappropriate outcome assessor blinding | 10 (9.8) | 0 | 2 (6.1) | 2 (6.9) | 0 | 5 (55.6) | 0 | 2 (10.0) | 1 (6.3)
Imbalance in use of cointerventions between groups | 5 (4.9) | 1 (1.9) | 1 (3.0) | 3 (10.3) | 2 (12.5) | 0 | 0 | 0 | 0
Described and acceptable drop out rates^*^ | 47 (46.1) | 27 (50.9) | 12 (36.4) | 19 (65.5) | 10 (62.5) | 5 (55.6) | 7 (77.8) | 14 (70.0) | 10 (62.5)
Unacceptable drop out rates | 45 (44.1) | 14 (26.4) | 6 (18.2) | 3 (10.3) | 2 (12.5) | 1 (11.1) | 1 (11.1) | 2 (10.0) | 1 (6.3)
Similarity of timing in assessment of outcomes between groups | 92 (90.2) | 41 (77.4) | 27 (81.8) | 24 (82.8) | 15 (93.8) | 9 (100.0) | 8 (88.9) | 19 (95.0) | 14 (87.5)
Reporting of intention-to-treat analysis | 30 (29.4) | 13 (24.5) | 10 (30.3) | 12 (41.4) | 5 (31.3) | 2 (22.2) | 4 (44.4) | 10 (50.0) | 7 (43.8)
Absence of selected outcome reporting | 39 (38.2) | 26 (49.1) | 17 (51.5) | 20 (69.0) | 10 (62.5) | 6 (66.7) | 5 (55.6) | 13 (65.0) | 11 (68.8)
Selected outcome reporting bias | 17 (16.7) | 8 (15.1) | 10 (30.3) | 5 (17.2) | 2 (12.5) | 3 (33.3) | 4 (44.4) | 4 (20.0) | 4 (25.0)
Total Score of Risk of Bias (max 13) Median (IQR) | 4 (1, 3) | 4 (3, 6) | 2 (3, 6) | 3 (4, 7) | 7 (4, 7) | 3 (5, 7) | 8 (3, 6) | 6 (5, 8) | 5 (3, 6)

^*^Item number # 9 of the Cochrane risk of bias tool: the number of participants who were included in the study but did not complete the observation period or were not included in the analysis must be described and reasons given. If the percentage of withdrawals and drop-outs does not exceed 20% for short-term follow-up and 30% for long-term follow-up and does not lead to substantial bias a “yes” is scored. (N.B. these percentages are arbitrary, not supported by literature).

### Population Characteristics of RCTs

The majority of trials included adult men and women aged 18 – 65 years. Three trials included only male and three trials included only female participants. Nine trials included older adults aged 55 and older.

Acupuncture. In total, 15,187 participants were included in the LBP and NP trials. The largest trial was conducted in Germany and included a total of 3,093 participants with chronic nonspecific low back pain. This trial reported efficacy and cost effectiveness and is discussed in detail in respective sections of the review. In 97 trials, subjects had nonspecific pain and in the remaining 91 trials subjects had specific pain.

Ninety-two trials enrolled subjects with identified or specific cause of pain such as disc perturbation, whiplash, cervicogenic headache, or underlying neurological causes. Details of these conditions can be found in Tables 1.1 – 1.8 (low back pain) and 2.1- 2.8 (neck pain) in Appendix C, and throughout the results section.

Manual treatments (spinal manipulation, mobilization and combined treatment). In total, 22,638 subjects were included in 100 trials. The majority of these trials (90 trials) included subjects with nonspecific pain. Details of these conditions can be found in Tables 1.9– 1.34 (low back pain) and 2.9- 2.18 (neck pain) in Appendix C, and throughout the results section.

Massage. In total, 4,050 subjects were included in 35 trials for treatment of LBP or NP. In 24 of the trials, subjects had nonspecific pain and in the remaining 11 trials subjects had specific pain (whiplash, myofascial pain, and other causes). Details of these conditions can be found in Tables 1.35– 1.40 (low back pain) and 2.19- 2.26 (neck pain) in Appendix C, and throughout the results section.

### Interventions and Control Treatments

Acupuncture. In 155 acupuncture trials, a large variety of methods of acupuncture treatments were used to compare the effect of acupuncture versus control treatments. The control treatments in these trials included active (i.e. physical modalities and exercise) or inactive treatments (i.e. placebo, no treatment). Details of treatment techniques and controls used can be found in Tables 1.1 – 1.8 (low back pain) and 2.1- 2.8 (neck pain) in Appendix C. The treatment providers for acupuncture trials were trained or licensed acupuncturists (27 trials), general practitioners or physicians with especial training in acupuncture (41 trials), neuropathy physicians (nine trials), general practitioners (five trials), and trained physiotherapists (four trials). In the majority of foreign language publications, particularly in Chinese trials, the treatment provider was referred as “therapist” (17 trials). The information about treatment provider was not reported for 85 trials. Specific details about treatment providers, years of experience (when reported), treatment duration, and outcomes assessed in each trial are presented in Appendix I.

Manual treatment (spinal manipulation, mobilization and combined treatment). In total, 101 primary trials used techniques of manipulation, mobilization or combination of both for treatment of low back, thoracic and neck pain. The details of treatment techniques and control interventions (active and inactive) used in these trials can be found in Tables 1.9 – 1.34 (low back pain) and 2.9 - 2.18 (neck pain) in Appendix C. In 32 trials, spinal manipulation or mobilization was provided by experienced and licensed chiropractors. In the remaining studies manipulation or mobilization was provided by physical therapists (17 trials), general practitioners (five trials), licensed or qualified manual therapy practitioners (six trials), physical therapists with manual therapy training (three trials), clinicians or experienced clinicians (four trials), neurologists or rheumatologists with chiropractic training (three trials), folk healers (one trial), and osteopaths (one trial). The information regarding treatment provider was not reported for the remaining 29 trials. Specific details about treatment providers, years of experience (when reported), treatment duration, and outcome assessed in each trial, are presented in Appendix I.

Massage. In total, 35 studies used massage for treatment of LBP, or NP. Details of treatment techniques and control interventions (active and inactive) used in these trials can be found in Tables 1.35 – 1.40 (low back pain) and 2.19 - 2.26 (neck pain) in Appendix C. In eight trials, treatment providers were licensed or experienced massage therapists. In the remaining trials, treatment of massage was provided by physical therapists (five trials), reflexologists, acupressure therapists, folk healers (four trials), general practitioners (four trials), manual therapists (two trials), experienced bone setters (one trial), and chiropractic students (one trial). For the remaining 10 trials, the information on treatment providers was not reported. Specific details about treatment providers, years of experience (when reported), treatment duration, and outcome assessed for each trial are presented in Appendix I.

## KQ1 What is the Efficacy, Effectiveness and Cost-effectiveness of the Most Prevalent Types of Practitioner-based Manual CAM Therapies Compared to Other CAM Therapies, Conventional Therapies, Placebo, no Treatment, or Wait List in Improving Outcomes in Patients With Nonspecific and Certain Specific Types of Back and Neck Pain?

### Efficacy & Effectiveness

#### 1 Acupuncture for Treatment of Low Back Pain

We included 105 trials in this section. Results of 15 trials were reported in multiple publications (Table 3).

Population/trial characteristics. The studies were conducted in Australia (four)52,140-142, Austria (one)143, Canada (two)144,145, China (54)134,138,146-174,175-197, Germany (six)22,24,37,99,198,199 Hong Kong (one)200, Iran (one)201, Ireland (four)136,146,202,203, Italy (two)204,205, Japan (15)121,206-215,215-218, Korea (one)219, Norway (one),220 Pakistan (one)221, Sweden (two)27,222, UK (three)53,110,223, and United States (eight)29,49,88,224-228.

The proportions of men and women were similar in 46 studies (40 percent - 60 percent). In 14 studies there were a greater proportion of men (> 60 percent) and in 15 studies women were the majority (> 60 percent). One study recruited only women,219 and another one only men.144 In six studies the proportion of men and women between the arms was not similar.140,197,209,209,218,228

The majority of trials (94 percent) recruited general adult age population (18 – 60 years old). Seven studies recruited only elderly subjects (60 years or older).53,207,208,216,217,226,227

Information on racial composition or ethnicity was reported for six studies.29,110,198,224,226,228 The Asian trials (72 studies) did not report the racial composition and was assumed to be 100 percent Asian.

In total 15,162 participants with LBP were randomized to acupuncture or control groups. The sample size in these trials varied from nine217 to 2841^24^ participants.

In the majority of trials (90 percent), acupuncture (various methods of needling techniques including electro-acupuncture) was used alone (95 studies), whereas in the remaining trials, it was used in combination with ‘other treatments’ (11 studies).99,144,158,161,172,185,193,198,200,216,226 The comparison arm in these trials was the same ‘other treatment.’ Table 6 presents the control interventions in the included studies.

Table 6 Acupuncture for treatment of low back pain- Control interventions

Type of control group | Cause of Pain | N studies | Detail of Control intervention
1- Nonactive Control treatments
Placebo/sham | Nonspecific | 20 | Non penetrating needling202,206,207 Superficial needling37, with injection of anesthetics and no stimulation142 Superficial needling at nonacupuncture points 22,99,203without stimulation or ‘de qi’198 Guided tube: with tapping on the tube206,210,212,213,without tapping156, with toothpick inside the tube228 Needling at nonacu points145,218 Sham TENS27,88,223 Sham EMG225 Not described197
Placebo/sham | Specific | 3 | Superficial needling with injection of lidocaine at nonacu points141 Sham TENS201 Gentle tapping162
No-treatment or waiting list | Nonspecific | 4 | No acupuncture24 Waiting list22,222 Delayed acupuncture227
2- Active Controls
Exercise/physical activity | Nonspecific | 1 | Standard exercise program200
Exercise/physical activity | Specific | 0 | NA
Physical modalities | Non Specific | 5 | TENS: Home treatment applied at acu-points121,209, details not reported53, applied over centre of pain,88 TENS with acupuncture216
Physical modalities | Specific | 1 | TENS on selected tender points alone176,
Physiotherapy | Nonspecific | 2 | Posture training aimed to remove muscle imbalance- according to Bruegger-concept198 Physical modalities such as light, electricity or heat163
Physiotherapy | Specific | 1 | Physical modalities such as hot packs, ultrasound, short-wave diathermy, and TENS in addition to muscle strengthening201
Traction | Nonspecific | 0 | NA
Traction | Specific | 1 | Traction,158,193,229 and rotatory manipulation159
Education/Self care | Non Specific | 1 | Self care education booklet and videotapes29,228
Education/Self care | Specific | 0 | NA
Manual treatment | Non Specific | 6 | Massage (acupressure) and ethyl chloride spray49, Swedish massage 29 Manipulation and/or mobilization224 Manipulation52,140 Massage and mobilization161 Mobilization or manipulation (and oral medication)164
Manual treatment | Specific | 0 | NA
Standard care or GP | Non Specific | 5 | Physiotherapy/exercise, medication, and advise37,99,110,224,226
Standard care or GP | Specific | 1 | Standard care (specific methods not reported)144
Medication | Non Specific | 7 | Oral analgesics,52,140,214,220,221 Chinese herbal medication,175 topical analgesics216
Medication | Specific | 6 | Oral analgesics, 134,138,146,186 intramuscular injection of analgesics154,195
Other method of acupuncture | Non Specific | 17 | Various method of needling on acu-points,27,49,218,219,225,230 alternative acu-points, 153,168,174,204,211,215,217 addition or use of warming needle/Moxibustion,215 non local points, superficial/deep needling,143 various dosing regiment,136,204,227 auricular, or alternative auricular technique143 dry needling (vs. two techniques of trigger point injection with lidocaine)49, personalized (vs. standard),231
Other method of acupuncture | Specific | 30 | Needling on muscle tendons,147, various method of needling on acu-points,150,162,166,170,194 alternative acupoints148,149,151,157,160,165,169,171,182,183,190,195,219 addition or use of warming needle/Moxibustion,152,177,181 non local points,154,179,184,187 superficial/deep needling, 178,205,208 fly-probing 189
Active treatment when compared with combination of same active treatment with acupuncture | Non Specific | 6 | Standard care (continued usual care: NSAIDs, muscle relaxant, paracetamol and back exercises), 226 orthopedic therapy, 99 exercise,200 physiotherapy (not described),198 TENS,216
Active treatment when compared with combination of same active treatment with acupuncture | Specific | 9 | Standard care (physiotherapy, remedial exercises, and occupational therapy)144 Traction,158,159,192,193 Massage,161,172,185,232
Acupuncture in combination with another treatment | Non Specific | 1 | TENS216
Acupuncture in combination with another treatment | Specific | 5 | Traction, 159,188 massage,232 injection and massage,191 cupping,192

Acu=acupuncture; EMG=electromyography; GP=general practitioner care; NA= not applicable; TENS=transcutaneous electrical nerve stimulation

Treatments were scheduled for one, two or three courses, each course ranging from 5 to 15 days in duration. The frequency of treatments in most studies was once a day consecutively for the duration of the study course. The number of acupuncture treatments across the studies was fewer than10,^160,168,170,181^ 10 - 20,^138,149,153,162-164,166,167,171,174-177,194,197^ and 21 - 45.^134,150,184,190^ The number of treatments in Chinese studies varied. Three of these studies did not report this information.156,180,195

The frequency of treatment in the remaining studies that reported this data were the following: One treatment,49,206,210,212,213,218,225 One to two sessions per week (up to 18 treatments in total),22,24,37,52,88,121,121,136,140-142,144,145,155,160,199,202,205,208,209,211,211,214,214,217,222,224,228,233 three sessions per week (up to 15 treatments in total),151,197,200,201,207,207,219 four sessions per week (12 treatments in total),99 and five sessions per week (up to 21 treatments in total).150,163,198,226

Risk of bias. The risk-of-bias graph for the trials included in this sub-section is presented in Figure 3. All trials were randomized. The adequate method of randomization and treatment allocation concealment was reported for about 44.0 percent and 20.0 percent of the trials, respectively. In 68.0 percent of the trials, the subjects’ baseline characteristics distribution across the treatment arms was similar (i.e., balanced). In one trial,53 the baseline distribution of VAS score was higher in the acupuncture versus TENS group (140 versus 101). For at least half of the trials, it was unclear whether or not the subjects and assessors were blinded to the type of treatment. About 47.0 percent of the trials reported acceptable drop-out rate. In one trial,140 the drop out rate in acupuncture group was very high (52.0 percent). Results based on intention-to-treat analysis were explicitly reported for about 30.0 percent of the trials.

Figure 3 Risk of bias score (%)

Figure 3 depicts the Risk of bias score percents as a bar graph. For each of the 13 questions below, a solid black line represents Yes, a gray line, No, and a dotted line, Unclear. At the bottom, left to right, are the percentages 0%, 20%, 40%, 60% 80%, and 100%. Q1 is Yes 0-just over 40%, No between just over 40% and nearly 60%, and Unclear, nearly 60% to 100%. Q2 is Yes 0-20%, No 20%-about 30%, and Unclear, about 30% to 100%. Q3 is Yes 0%- about 70%, No about 70% to just under 80%, and Unclear just under 80% to 100%. Q4 is Yes 0% to about 25%, No about 25% to about 55%, and Unclear about 55% to 100%. Q5 is Yes 0% to less than 5%, No less than 5% to about 50%, and Unclear about 50% to 100%. Q6 is Yes 0% to about 30%, No about 30% to 40%, and Unclear 40% to 100%. Q7 is Yes 0% to just under 60%, No just under 60% to just over 60%, and Unclear just over 60% to 100%. Q8 is Yes 0% to just under 30%, No just under 30% to just under 40%, and Unclear just under 40% to 100%. Q9 is Yes 0% to about 50%, No about 50% to 90%, and Unclear 90% to 100%. Q10 is Yes 0% to about 90%, No about 90% to about 95%, and Unclear about 95% to 100%. Q11 is Yes 0% to about 30%, No about 30% to about 45%, and Unclear about 45% to 100%. Q12 is Yes 05 to 40%, No 40% to just under 60%, and Unclear just under 60% to 100%. Q13 is Yes 0% to about 3%, No about 3% to about 15%, and Unclear, about 15% to 100%.

The data for selected items of the risk of bias tool across the CAM interventions (acupuncture; spinal manipulation; spinal mobilization; combination of manipulation and mobilization; and massage therapy) is displayed in table 7.1 of Appendix G.

1. Was the method of randomization adequate?
2. Was the treatment allocation concealed?
3. Were the groups similar at baseline regarding the most important prognostic indicators?
4. Was the patient blinded to the intervention?
5. Was the care provider blinded to the intervention?
6. Was the outcome assessor blinded to the intervention?
7. Were cointerventions avoided or similar?
8. Was the compliance acceptable in all groups?
9. Was the drop-out rate described and acceptable?
10. Was the timing of the outcome assessment in all groups similar?
11. Did the analysis include an intention-to-treat analysis?
12. Are reports of the study free of suggestion of selective outcome reporting?
13. Is this study free of any other bias?

Efficacy results. A summary of the key results is presented in Table 7. For further detail of the trials please see the evidence tables. (Appendix C, table 1.1 – table 1.8)

Table 7 Key results – Acupuncture treatment in patients with low back pain

Acupuncture therapy | Duration of pain | Cause of pain | Outcome | Risk-of-bias | Precision of the pooled estimate | Consistency | Directness | Finding | GRADE^ψ^
Acu vs. No Tx | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Acu vs. No Tx | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Acu vs. No Tx | Chronic | S | - | - | - | - | - | - | Insufficient
Acu vs. No Tx | Chronic | NS | VAS: C | M | Precise (3)^£^24,222,227 | Yes | Direct | >SS | Moderate
Acu vs. No Tx | Chronic | NS | PDI: B22 | L | - | NA | Direct | > SS | Moderate
Acu vs. No Tx | Chronic | NS | HFAQ: B22,24 | M | - | Yes | Direct | > SS | Moderate
Acu vs. No Tx | Chronic | NS | SF-36: B22,24 | M | - | Yes | Direct | > SS | Moderate
Acu vs. No Tx | Chronic | NS | ROM (ext, flx): B, D222 | M | - | NA | Indirect | > SS | Low
Acu vs. No Tx | Mixed/Unknown | S | - | - | - | - | - | - | Insufficient
Acu vs. No Tx | Mixed/Unknown | NS | - | - | - | - | - | - | Insufficient
Acu vs. PL | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Acu vs. PL | Acute/subacute | NS | VAS: C202,212 | M | - | Yes | Direct | = S-NS | Moderate
Acu vs. PL | Acute/subacute | NS | RMDQ: C202 | M | - | NA | Direct | = S-NS | Low
Acu vs. PL | Acute/subacute | NS | Use of medication: B202 | M | - | NA | Direct | > SS | Low
Acu vs. PL | Chronic | S | - | - | - | - | - | - | Insufficient
Acu vs. PL | Chronic | NS | VAS: B | M | Precise (10)22,37,99,141,156,197,198,203,206,228 | Yes | Direct | > SS | Moderate
Acu vs. PL | Chronic | NS | VAS: C | M | Precise (3)27,37,99 | Yes | Direct | = S-NS | Moderate
Acu vs. PL | Chronic | NS | VAS: D | M | Precise (3)22,27,228 | Yes | Direct | = S-NS | Moderate
Acu vs. PL | Chronic | NS | VAS: E | M | Precise (4)22,27,198,228 | Yes | Direct | = S-NS | Moderate
Acu vs. PL | Chronic | NS | SF-36: B22,203 | M | - | No | Direct | => | Low
Acu vs. PL | Chronic | NS | SF-36: D22 | L | - | NA | Direct | = S-NS | Moderate
Acu vs. PL | Chronic | NS | MPQ: B141,203 | M | - | Yes | Direct | = S-NS | Moderate
Acu vs. PL | Chronic | NS | Use of medication: B141 | M | - | NA | Indirect | = S-NS | Low
Acu vs. PL | Chronic | NS | RMDQ: B | M | Imprecise (2)197,228 | Yes | Direct | = S-NS | Moderate
Acu vs. PL | Chronic | NS | % pts on sick leave: B | M | Imprecise (2)27,99 | Yes | Indirect | = S-NS | Low
Acu vs. PL | Chronic | NS | % pts with global improvement: C | M | Imprecise (2)27,99 | No | Direct | = S-NS | Low
Acu vs. PL | Chronic | NS | % pts with global improvement: D | M | Imprecise37,203 | Yes | Direct | = S-NS | Moderate
Acu vs. PL | Chronic | NS | HFAQ: B | L | Precise (2)22,37 | No | Direct | < SS | Moderate
Acu vs. PL | Chronic | NS | HFAQ: D | L | Precise (2)22,37 | No | Direct | < SS | Moderate
Acu vs. PL | Mixed | S | - | - | - | - | - | - | Insufficient
Acu vs. PL | Mixed | NS | - | - | - | - | - | - | Insufficient
Acu vs. PL | Unknown | S | - | - | - | - | - | - | Insufficient
Acu vs. PL | Unknown | NS | VAS: B210,218 | M | - | Yes | Direct | > SS | Moderate
Acu vs. PL | Unknown | NS | % pts who improved: B145 | H | - | NA | Direct | = S-NS | Low
E-Acu vs. PL | Acute/subacute | S | - | - | - | - | - | - | Insufficient
E-Acu vs. PL | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
E-Acu vs. PL | Chronic | S | VAS: B201 | H | - | NA | Direct | > SS | Low
E-Acu vs. PL | Chronic | NS | Trunk ext: C88 | H | - | NA | Indirect | > SS | Low
E-Acu vs. PL | Chronic | NS | Trunk ext: C88 | H | - | NA | Indirect | > SS | Low
E-Acu vs. PL | Mixed/Unknown | S | - | - | - | - | - | - | Insufficient
E-Acu vs. PL | Mixed/Unknown | NS | - | - | - | - | - | - | Insufficient
Acu vs. Med | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Acu vs. Med | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Acu vs. Med | Chronic | S | - | - | - | - | - | - | Insufficient
Acu vs. Med | Chronic | NS | VAS: B | H | Precise (4)51,140,216,221 | No | Direct | = S-NS | Low
Acu vs. Med | Chronic | NS | Oswestry: B | H | Imprecise (2)51,140 | No | Direct | = S-NS | Low
Acu vs. Med | Mixed | S | % pts cured: B134,146 | H | - | Yes | Indirect | => | Low
Acu vs. Med | Mixed | S | Time (in min) to analgesic effect: B154,195 | M | - | Yes | Direct | > SS | Moderate
Acu vs. Med | Mixed | S | Duration (in hr) of analgesic effect: B154,195 | M | - | Yes | Direct | > SS | Moderate
Acu vs. Med | Mixed | NS | - | - | - | - | - | - | Insufficient
Acu vs. Med | Unknown | S | - | - | - | - | - | - | Insufficient
Acu vs. Med | Unknown | NS | % pts who improved: B49 | M | - | NA | Direct | = S-NS | Low
E-Acu vs. Med | Acute/subacute | S | - | - | - | - | - | - | Insufficient
E-Acu vs. Med | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
E-Acu vs. Med | Chronic | S | - | - | - | - | - | - | Insufficient
E-Acu vs. Med | Chronic | NS | VAS: B221 | H | - | NA | Direct | > SS | Low
E-Acu vs. Med | Mixed | S | % pts who improved: B138,139 | M | - | Yes | Direct | > SS | Moderate
E-Acu vs. Med | Mixed | S | Raising straight leg: B138 | M | - | NA | Indirect | > SS | Low
E-Acu vs. Med | Mixed | NS | - | - | - | - | - | - | Insufficient
E-Acu vs. Med | Unknown | S | % pts who improved: B186 | H | - | NA | Direct | > SS | Low
E-Acu vs. Med | Unknown | NS | - | - | - | - | - | - | Insufficient
Acu vs. PT | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Acu vs. PT | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Acu vs. PT | Chronic | S | - | - | - | - | - | - | Insufficient
Acu vs. PT | Chronic | NS | Oswestry: B163 | M | - | NA | Direct | > SS | Low
Acu vs. PT | Chronic | NS | % pts cured: B163 | M | - | NA | Indirect | = S-NS | Low
Acu vs. PT | Mixed | S | - | - | - | - | - | - | Insufficient
Acu vs. PT | Mixed | NS | - | - | - | - | - | - | Insufficient
Acu vs. PT | Unknown | S | - | - | - | - | - | - | Insufficient
Acu vs. PT | Unknown | NS | - | - | - | - | - | - | Insufficient
E-Acu vs. PT | Acute/subacute | S | - | - | - | - | - | - | Insufficient
E-Acu vs. PT | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
E-Acu vs. PT | Chronic | S | VAS: B201 | H | - | NA | Direct | > SS | Low
E-Acu vs. PT | Chronic | NS | - | - | - | - | - | - | Insufficient
E-Acu vs. PT | Mixed | S | - | - | - | - | - | - | Insufficient
E-Acu vs. PT | Mixed | NS | - | - | - | - | - | - | Insufficient
E-Acu vs. PT | Unknown | S | - | - | - | - | - | - | Insufficient
E-Acu vs. PT | Unknown | NS | - | - | - | - | - | - | Insufficient
Acu vs. ST | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Acu vs. ST | Acute/subacute | NS | RMDQ: B, C, D224 | M | - | NA | Direct | = S-NS | Low
Acu vs. ST | Chronic | S | - | - | - | - | - | - | Insufficient
Acu vs. ST | Chronic | NS | RMDQ: C, D226,228 | M | - | Yes | Direct | > SS | Moderate
Acu vs. ST | Chronic | NS | VAS: C, D226,228 | M | - | Yes | Direct | > SS | Moderate
Acu vs. ST | Chronic | NS | HFAQ: D37 | L | - | NA | Direct | > SS | Moderate
Acu vs. ST | Chronic | NS | SF-12: D37 | L | - | NA | Direct | > SS | Moderate
Acu vs. ST | Chronic | NS | SF-36-bodily pain: E110 | M | - | NA | Direct | > SS | Low
Acu vs. ST | Chronic | NS | Oswestry: E110 | M | - | NA | Direct | = S-NS | Low
Acu vs. ST | Chronic | NS | MPQ: E110 | M | - | NA | Direct | = S-NS | Low
Acu vs. ST | Chronic | NS | Utilization of conventional care110,112 | M | - | NA | Indirect | = S-NS | Low
Acu vs. ST | Mixed | S | - | - | - | - | - | - | Insufficient
Acu vs. ST | Mixed | NS | - | - | - | - | - | - | Insufficient
Acu vs. ST | Unknown | S | - | - | - | - | - | - | Insufficient
Acu vs. ST | Unknown | NS | - | - | - | - | - | - | Insufficient
Acu vs. Man | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Acu vs. Man | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Acu vs. Man | Chronic | S | - | - | - | - | - | - | Insufficient
Acu vs. Man | Chronic | NS | VAS: B | H | Precise (2)51,140 | No | Direct | < SS | Low
Acu vs. Man | Mixed/Unknown | S | - | - | - | - | - | - | Insufficient
Acu vs. Man | Mixed/Unknown | NS | - | - | - | - | - | - | Insufficient
Acu vs. Ma | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Acu vs. Ma | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Acu vs. Ma | Chronic | S | - | - | - | - | - | - | Insufficient
Acu vs. Ma | Chronic | NS | RMDQ: B, D29 | M | - | NA | Direct | < SS | Low
Acu vs. Ma | Chronic | NS | VAS: B, D29 | M | - | NA | Direct | < SS | Low
Acu vs. Ma | Chronic | NS | % pts using medication: D29 | M | - | NA | Direct | = S-NS | Low
Acu vs. Ma | Chronic | NS | Conventional care (number of provider visits): D29 | M | - | NA | Indirect | = S-NS | Low
Acu vs. Ma | Chronic | NS | Conventional care (number of imaging studies): D29 | M | - | NA | Indirect | = S-NS | Low
Acu vs. Ma | Mixed/Unknown | S | - | - | - | - | - | - | Insufficient
Acu vs. Ma | Mixed/Unknown | NS | - | - | - | - | - | - | Insufficient
Acu vs. TENS | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Acu vs. TENS | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Acu vs. TENS | Chronic | S | - | - | - | - | - | - | Insufficient
Acu vs. TENS | Chronic | NS | VAS: B | M | Imprecise (2)53,216 | No | Direct | = S-NS | Low
Acu vs. TENS | Chronic | NS | VAS: C | M | Precise (2)53,216 | No | Direct | = S-NS | Low
Acu vs. TENS | Mixed/Unknown | S | - | - | - | - | - | - | Insufficient
Acu vs. TENS | Mixed/Unknown | NS | - | - | - | - | - | - | Insufficient
E-acu vs. TENS | Acute/subacute | S | - | - | - | - | - | - | Insufficient
E-acu vs. TENS | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
E-acu vs. TENS | Chronic | S | - | - | - | - | - | - | Insufficient
E-acu vs. TENS | Chronic | NS | - | - | - | - | - | - | Insufficient
E-acu vs. TENS | Mixed | S | - | - | - | - | - | - | Insufficient
E-acu vs. TENS | Mixed | NS | VAS: B121,209 | M | - | No | Direct | => | Low
E-acu vs. TENS | Unknown | S | - | - | - | - | - | - | Insufficient
E-acu vs. TENS | Unknown | NS | - | - | - | - | - | - | Insufficient
Acu vs. E-acu | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Acu vs. E-acu | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Acu vs. E-acu | Chronic | S | - | - | - | - | - | - | Insufficient
Acu vs. E-acu | Chronic | NS | VAS: B, C143 | M | - | NA | Direct | < SS | Low
Acu vs. E-acu | Chronic | NS | N of analgesic tablets: B, C143 | M | - | NA | Direct | < SS | Low
Acu vs. E-acu | Mixed | S | - | - | - | - | - | - | Insufficient
Acu vs. E-acu | Mixed | NS | - | - | - | - | - | - | Insufficient
Acu vs. E-acu | Unknown | S | % pts cured: B186 | M | - | NA | Indirect | < SS | Low
Acu vs. E-acu | Unknown | NS | - | - | - | - | - | - | Insufficient

S=specific; NS=nonspecific; SS=statistically significant; S-NS=statistically nonsignificant; Man=manipulation; Acu=acupuncture; Ma=massage; Mob=mobilization; PL=placebo; Tx=treatment. Med=medication(s); Int=intervention; PT=physiotherapy; ST=standard therapy; E-acu=electro-acupuncture; MR=muscle relaxation; TENS= transcutaneous electrical nerve stimulation; Ex=exercise; TrP=trigger point; VAS=visual analog scale; RMDQ=Roland Morris Disability scale; NHP=Nottingham Health Profile; PPT= pressure pain threshold; HFAQ=Hanover functional ability questionnaire; MPQ=McGill pain questionnaire; ext=extension; flx=flexion; rot=rotation; PDI=pain disability index; min=minute(s); hr(s)=hour(s); L=low; M=medium; H=high; pt(s)=patient(s); SF=short-form; NPQ=neck pain questionnaire; GWBS=global well-being scale; SLR=straight leg raising; GPE= Global perceived effect; NSAIDS=nonsteroidal antiinflammatory drugs; FTF=finger-to-floor; SF-PQ=short form pain questionnaire; PRI=pain rating index; PPI=present pain intensity; NA=not applicable

^ψ^ Grade (High, moderate, low, and insufficient)

^£^ Number of pooled trials

B = immediate post-treatment

C = short-term post-treatment

D = intermediate-term post-treatment

E = long-term post-treatment

H = high

L = low

M = medium

- No evidence

= Similar beneficial effect

> Favors treatment A over treatment B

< Favors treatment B over treatment A

><, =>, <= Inconsistent beneficial effect

Population with acute/subacute pain. There were nine trials of patients with acute or subacute LBP included in this sub-section.152,160,167-169,202,212,220,224 Of these, five trials studied patients with nonspecific LBP167,202,212,220,224 and four trials – patients with LBP due to disc protrusion or lumbar sprain.152,160,168,169

Subjects with specific pain.

Acupuncture versus placebo. No relevant studies were identified.

Acupuncture versus no treatment. No relevant studies were identified.

Acupuncture (type 1) versus acupuncture (type 2). In three trials, different modalities of electro-acupuncture (local single-point versus conventional)160 and acupuncture (needling Xi-Cleft points versus conventional needling;169 warming needle moxibustion versus conventional needling152) were compared in treating subjects with LBP due to disc protrusion. In all three trials, experimental treatment modalities (local single-point electro-stimulation, needling Xi-Cleft points, and needle warming moxibustion) were shown to be more effective than conventional acupuncture (or electro-acupuncture) in improving immediate post-treatment pain (VAS score, therapeutic effect – the absence of pain) or disability (Oswestry Disability Index score).152,160,169 In one trial,168 in subjects with pain due to lumbar sprain, needling at Yanglao (S16) was associated with a numerically higher response rate (percent subjects free of lumbar pain with tenderness relieved by 80.0 percent, lumbar flexion 110°, extension 30°, free and unlimited squatting) compared to needling at paravertebral or Ashi acu-points (94.4 percent versus 69.7 percent, p < 0.01). In the same trial, earlier administration of treatment tended to produce better response rates irrespective of the type of acupuncture. No pain intensity or disability outcomes were reported.

Acupuncture versus other treatments. No relevant studies were identified.

Acupuncture versus medication. In one trial,220 there was no difference immediately, short-term, or intermediate-term after the end of treatment between acupuncture and Naproxen 500 mg, taken twice daily for 10 days, in measures of pain (VAS).

Acupuncture + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Acupuncture versus placebo. The effects of acupuncture and placebo (nonpenetrating needling, or guided tube) were compared in two trials.202,212 Although in the first trial,202 immediately or 3 months after the treatment subjects in the acupuncture group had numerically improved degree of disability (RMDQ score) and pain (mean VAS score: 1-100) compared to subjects who received placebo (sham acupuncture), these differences were not statistically significant due to a low power of this trial (RMDQ score difference at 3 months: 2.6, 95 percent CI: -0.7, 5.9 and VAS score difference at 3 months: 10.6, 95 percent CI: -4.1, 25.3). In the same trial, at the end of treatment, subjects randomized to acupuncture were taking significantly fewer pain medication tablets for LBP compared to those in the placebo-treated group (1.0 ± 0.3 versus 4.2 ± 0.6, p < 0.05).

In the other trial,212 acupuncture, compared to placebo, was associated with a nonsignificantly lower pain intensity VAS score (49.9 ± 22.2 versus 51.8 ± 26.1, p > 0.05).

Acupuncture versus no treatment. No relevant studies were identified.

Acupuncture versus another type/method of the same CAM. No relevant studies were identified.

Acupuncture versus other treatments. In one trial,224 the addition of patients’ choice for acupuncture to usual care did not improve the degree of disability (RMDQ score) compared to usual care alone immediately, shortly, or intermediate-term post-treatment.

Acupuncture versus medication. No relevant studies were identified.

Acupuncture (type 1) versus acupuncture (type 2). The combination of acupuncture, pricking collateral, cupping, and moxibustion was shown to be associated with greater improvement in complete curative effect (i.e., complete relief of the severe pain and positive symptoms, recovery of motility and other functions, and ability to engage in normal work and life) compared to acupuncture alone or combined with cupping.167

Population with chronic pain. A total of 42 trials were included in this section, the majority of which studied subjects with nonspecific LBP (36 studies).22,24,27,29,37,52,53,88,99,136,140-143,155,156,163,174,197,198,200,203,204,206,207,211,213,214,216,217,222,223,225-228 The remaining six trials included subjects with LBP due to specific causes (e.g., myofascial pain syndrome, spondylitis, disc protrusion, sciatica, injuries/fractures).144,162,201,205,208,221

Subjects with specific pain.

Acupuncture versus placebo. One trial compared the effects of electro-acupuncture and placebo (sham TENS) on the reduction of pain intensity in subjects with sciatica.201 The use of electro-acupuncture was significantly more effective in reducing pain or sciatica at short term followup compared to placebo.

Acupuncture versus no treatment. No relevant studies were identified.

Acupuncture versus another type/method of the same CAM. No relevant studies were identified.

Acupuncture versus other treatments. One trial compared the effects of electro-acupuncture to that of physiotherapy (hot packs, ultrasound, short wave diathermy, TENS, muscle stretching) in subjects with sciatica.201 The use of electro-acupuncture was found to be clinically and significantly more beneficial in reducing short-term post-treatment pain compared to physiotherapy201

Acupuncture versus medication. In one trial,221 the use of electro-acupuncture in patients with herniated lumbar disc was shown to be significantly beneficial in reducing pain intensity immediately after the treatment compared to 50 mg diclofenic (mean VAS, 1-100: 25.7 ± 2.3 versus 33.3 ± 2.5, p < 0.05).

Acupuncture (type 1) versus acupuncture (type 2). In two trials, different needling techniques were compared in subjects with spondylitis, and lumbar strain (soft tissue injury),162 or myofascial pain syndrome.205 In the first study,162 for the subgroup of patients with lumbar strain (soft-tissue injury) dermal needling was better than only acupuncture. For the subgroup of patients with hyperplastic spondylitis, body acupuncture was better than dermal needling.162 In the other study,205 in-depth needling205 had significantly better analgesic effect at 3 months followup compared to superficial needling in patients with myofascial pain syndrome. This beneficial effect was not apparent at the end of 8 treatment sessions.

In one additional trial,208 standard, deep, and superficial needling modalities applied to the trigger points were compared (insertion depth: 20 mm, 23 mm, 3 mm, respectively) with respect to immediate post-treatment reductions in pain intensity (VAS: 1-100) and disability (RMDQ scores) in elderly subjects with spondylosis, osteoporosis, or trauma. Although there was a numerical preponderance in favor of deep needling for pain intensity, the observed between-group differences were not statistically significant (VAS: 56.8 ± 25.1 versus 44.4 ± 19.1 versus 50.1 ± 32.5, p > 0.05). The mean RMDQ disability score was similar across the groups (4.2 ± 4.3 versus 4.2 ± 1.2 versus 4.3 ± 2.2).208

In one trial of higher risk of bias (20 patients),211 distal point needling for low-back pain of any duration was no different from local lumbar area needling for measures of pain, function and range of motion.

Subjects with nonspecific pain.

Acupuncture versus placebo. The effects of acupuncture and placebo were compared in 16 trials.22,27,37,88,99,141,142,156,197,198,203,206,207,213,223,228 The results of these trials were conflicting. In nine trials,27,88,99,156,206,207,213,223,228 acupuncture was significantly better than placebo in reducing pain intensity (VAS scores, percent subjects with improved pain or with relief ≥ 50 percent)27,88,99,206,207,223 or disability levels (RMDQ scores)207,228 immediately or shortly after the end of treatment. For example, in one trial,156 Fu’s subcutaneous needling was compared to placebo (sham-acupuncture) with respect to post-treatment reduction in motion-related pain (MRP score) and pain under pressure (PUP)., Fu’s subcutaneous needling compared to placebo produced significantly greater immediate post-treatment reductions on both MRP (2.66 ± 2.42 versus 0.54 ± 1.14) and PUP (2.38 ± 2.39 versus 0.36 ± 0.99). The placebo treatments used in these trials were toothpick inside the tube,228 sham TENS,27,88,223 nonpenetrating needling,206,207 superficial needling at nonacupuncture points,99 and guided tube.156,213

In contrast, results from six other trials indicated that acupuncture was not significantly better than placebo in reducing back pain (VAS scores: 0-100, modified MPQ, Von Korff Chronic Pain Grade Scale: 0-10), disability (PDI, HFAQ), or improving quality of life (SF-12 physical score) immediately or shortly (3 months) after the end of treatment.37,141,142,197,198,203 For example, in one of these trials141 although immediate mean post-treatment VAS score was numerically lower in the acupuncture versus placebo group, the between-group difference was not statistically significant (30.2 ± 3.0 versus 40.0 ± 3.8, p > 0.6). The degree of pain measured by MPQ also yielded nonsignificant between-group difference. In general, the use of analgesic medication and degree of disability (scale not specified) decreased, but did not differ between the two groups. The placebo used in these trials were superficial needling with injection of Lidocaine at nonacupuncture points,141 superficial needling at nonacupuncture points,198,203 superficial needling37, and injection of anesthetics and no stimulation.142 The placebo was not described for one trial.197

Moreover, in one trial,22 immediately after the end of treatment, acupuncture produced significantly greater improvements in pain (VAS scores: 34.5 versus 43.7, p = 0.03) and quality of life (SF-36 physical health domain: 40.5 versus 36.2, p < 0.004) compared to placebo, the differences in pain (VAS score: 38.4 versus 42.1, p = 0.39) and quality of life (SF-36 physical health domain: 39.3 versus 37.6, p = 0.27) were no more significant at four and 10 months post-treatment followup.22 The effects of acupuncture and placebo TENS were compared in two trials,27,203 in one of which acupuncture was shown to be similar to placebo-TENS in terms of pain relief (MPQ, VAS scores) or quality of life (SF-36),203 while the other trial27 showed that in short term post-treatment reduction in pain (VAS scores) was significantly greater in the acupuncture versus placebo-TENS group. There was no significant difference in pain intensity between the two groups at 4 months after the end of treatment (p = 0.12).

The meta-analyses indicated statistically significant pooled mean differences between the effects of acupuncture and placebo in reducing pain intensity (VAS scores) immediately (-0.59, 95 percent CI: -0.93, -0.25).22,37,99,141,156,197,198,203,206,228 (Figure 4). However, the short-term (-1.11, 95 percent CI: -2.33, 0.11),27,37,99 intermediate (-0.18, 95 percent CI: -0.85, 0.49),22,27,228 and long-term (-0.21, 95 percent CI: -0.64, 0.22)22,27,198,228 post-treatment mean VAS differences between acupuncture and placebo groups were not statistically significant (Figures 5-7). Note that the degree of heterogeneity for immediate and short-term post-treatment pooled estimates for the mean VAS score (Figures 4-5) is substantial (I^2^ range: 52.3 percent-85.0 percent), and therefore, these results warrant cautious interpretation.

Figure 4 Pain intensity (VAS score) – Immediate post-treatment

Figure 4 depicts Pain Intensity (VAS score), Immediate post-treatment. On the left is a chart with three headings--Study Name, Acupuncture (with two subheads, N and Mean (SD), and Placebo (with two subheads, N and Mean (SD)). Under study names is a list of study names. From left to right, Study Names, to Acupuncture N and Mean (SD) to Placebo (N and Mean SD), is the following information: Mendelson et al. 1983--36--3 (1.8)--41--4 (2.4); Leibling et al. 2002--35--2.1 (2.2) 40--3.2 (2.2); Molsberger et al. 2002--58--2.6 (2.1)--58--3.6 (1.9); Kerr et al. 2003--26--5.1 (2.2)--20--6.2 (3.1); Brinkhaus et al. 2006--140--3.5 (2.9), 70--4.4 (3); Inoue et al. 2006--15--4.7 (0.7)--16--5.5 (1.3); Fu et al. 2006--32--2.6 (2.6)--28--3.8 (2.3): Kwon et al. 2007--24--3.3 (1.6)--23--3.6 (1.5); Haake et al. 2007 370--4.9 (1.9)--375--5.1(1.9); Cherkin et al. 2009--158--3.3(2.5)--162--3(2.4); Pooled--894--blank--833--blank-- -0.59 (-0.93, -0.25). On the right is a chart depicting Difference in means and 95% CI. On the bottom is a horizontal line with the numbers, left to right, -10.00, -5.00, 0.00, 5.00 and 10.00. A vertical line runs up from 0.00 with bullets on bars representing each of the above studies. Two column heads are over the top of that chart with Favors Acupuncture on the left hand side with an arrow pointing left, and Favors Placebo on the right with an arrow pointing to the right. On the right is a vertical list--(from the top), -0.98 (-1.l96, -0.01); -1.1 (-2.1, -0.1); -1 (-1.73, -0.27); -1.04 (-2.57, 0.49); -0.92 (-1.75, -0.09); -0.8 (-1.54, -0.06); -1.23 (-2.48, 0.02); -0.25 (-1.13, 0.63); -0.24 (0.51, 0.03); 0.3 (-0.24, 0.84); -0.59 (-0.93, -0.25). On the bottom left of the chart is the following: Heterogeneity: Chi 2(superscript) = 18.9, df = 9 (P = 0.03); I 2(superscript) = 52.3%.

Figure 5 Pain intensity (VAS score) – Short-term post-treatment

Figure 5 depicts Pain Intensity (VAS score) in Short-term post-treatment. On the top are column headings, Study Name, Acupuncture (with subheads N and Mean (SD)), Placebo (with subheads N and Mean (SD)). On the right is another head, Difference in means and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -10.00, -5.00, 0.0, 5.00, 10.00. A vertical line runs up from 0.0 with bullets on bars representing the numbers in the studies. Above that on the left are the words Favors Acupuncture with an arrow pointing left, and on the right are the words Favors Placebo with an arrow pointing right. The results, left to right, are: Carlsson et al. 2001--34--5.2 (2.4)--16--6.4 (2.5)-- -1.2 (-2.64, -0.01); Molsberger et al. 2002--47--2.3 (2)--41--4.3 (2.3)-- -2 (-2.9, -0.1); Haake et al. 2007--373--4.54 (1.9)--376--4.85-- -0.31 (-0.59, 0.49)--Pooled--434--blank--433--blank-- -1.11 (-2.3, 0.11). On the bottom left of the chart are the words Heterogeneity: Chi 2(superscript) = 13.4, df = 2 (P < 0.05); I 2(superscript) = 85.0%.

Figure 6 Pain intensity (VAS score) – Intermediate-term post-treatment

Figure 6 depicts Pain Intensity (VAS score) for Intermediate-term post-treatment. On the left is a chart with three headings--Study Name, Acupuncture (with subheads N and Mean ((D)), and Placebo (with subheads N and Mean (SD)). On the right is another head, Difference in means and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -10.00, -5.00, 0.00, -5.00, 10.00. A vertical line runs up from 0.0 with bullets on bars representing the numbers in the studies. On the upper left of that chart are the words Favors Acupuncture with an arrow pointing left, and on the upper right of the chart are the words Favors Placebo with an arrow pointing right. The results, left to right, are: Carlsson et al. 2001--23--4.8 (2.2)--9--6.2 (3.0); -1.4 (-3.28, 0.48); Brinkhaus et al. 2006--140--3.8 (3.0)--70--4.2 (3.0)-- -0.l36 (-1.22, 05); Cherkin et al. 2009--158--3.7 (2.8)--162--3.5 (2.7)-- 0.2 (-0.38, 0.78); Pooled--321--blank--241--blank-- -0.18 (-0.85, 0.49). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 3.1, df = 2(P =0.20); I 2(superscript) 37.2%.

Figure 7 Pain intensity (VAS score) – Long-term post-treatment

Figure 7 depicts Pain Intensity (VAS score) for Long-term post-treatment. On the left is a chart with three headings--Study Name, Acupuncture (with subheads N and Mean (SD)), and Placebo (with subheads N and Mean (SD)). On the right is another head, Difference in means and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -10.00, -5.00, 0.00, -5.00, 10.00. A vertical line runs up from 0.0 with bullets on bars representing the numbers in the studies. On the upper left of that chart are the words Favors Acupuncture with an arrow pointing left, and on the upper right of the chart are the words Favors Placebo with an arrow pointing right. The results, left to right, are: Carlsson et al. 2001--21--4.2 (2.2)--6--5.4 (3.5)-- -1.2 (0-3.48, 1.08); Leibling et al. 2002--33--3.1 (1.8)--31--3.5 (2.2)-- -0.4 (-1.38, 0.58); Brinkhaus et al. 2006--137--3.9 (2.9)--68--4.5 (3)-- -0.57 (-1.43, 0.29); Cherkin et al. 2009--158--3.5 (2.7);--162--3.4 (2.7)--0.1 (-0.49, 0.69); Pooled--349--blank--267--blank-- -0.21 (-0.64, 022). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 2.6, df = 3(P =0.45): I 2(superscript) = 0.0%.

Based on our meta-analyses, there were no significant differences between acupuncture and placebo in improving disability (pooled mean RMDQ difference score; 0.81, 95 percent CI: - 0.27, 1.9)197,228 and reducing proportion of subjects on sick leave (pooled RR = 0.59, 95 percent CI: 0.23, 1.52),27,99 immediately after the treatment (Figures 8-9). Similarly, the proportion of patients with global improvement did not significantly differ in acupuncture and placebo groups in short- (pooled RR = 1.89, 95 percent CI: 0.93, 3.83)27,99 or intermediate-term (pooled RR = 1.10, 95 percent CI: 0.96, 1.26)37,203 post-treatment period (Figures 10-11). Moreover, two meta-analyses showed statistically significantly improved degree of functional disability on HFAQ score in favor of acupuncture over placebo at post-treatment immediate (4.00, 95 percent CI: 1.30, 6.80)22,37 or intermediate-term of followup (4.00, 95 percent CI: 1.10, 6.80)22,37 (Figures 12-13).

Figure 8 Disability (RMDQ score) – Immediate post-treatment

Figure 8 depicts Disability (RMDQ score) for Immediate post-treatment. On the left is a chart with three headings--Study Name, Acupuncture (with subheads N and Mean (SD)), and Placebo (with subheads N and Mean (SD)). On the right is another head, Difference in means and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -10.00, -5.00, 0.00, -5.00, 10.00. A vertical line runs up from 0.0 with bullets on bars representing the numbers in the studies. On the upper left of that chart are the words Favors Acupuncture with an arrow pointing left, and on the upper right of the chart are the words Favors Placebo with an arrow pointing right. The results, left to right, are: Kwon et al. 2007--24--5.16 (4.9)--23--4.92 (4.8)--0.24 (-2.5, 3.0); Cherkin et al. 2009--158--6.3 (5.7); 162--5.4 (4.9)--0.90 (-0.26, 2.1); Pooled--182--blank--185--blank--0.81 (-027, 1.9). On the lower right of the figure are the words Heterogeneity: Chi 2(superscript) = 0.18, df = 1 (P < 0.66); I 2(superscript) = 0.0%.

Figure 9 Proportion of subjects on sick leave - Immediate post-treatment

Figure 9 depicts Proportion of subjects on sick leave - Immediate post-treatment. On the left is a chart with three headings--Study Name, Acupuncture (with subhead n/N), and Placebo (with subhead n/M). On the right is another head, Relative risk and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, 0.1, 0.2, 0.5, 1, 2, 5, 10. A vertical line runs up from 1 with bullets on bars representing the numbers in the studies. On the upper left of that chart are the words Favors Acupuncture with an arrow pointing left, and on the upper right of the chart are the words Favors Placebo with an arrow pointing right. The results, left to right, are: Carlsson et al. 2001--6/13--7/13--0.86 (0.40, 1.86); Molsberger et al. 2002--3/21--5/11--0.31 (0.09, 1.08); Pooled--9/34--12/24--0.59 (0.23, 1.52). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 1.8, df = 1(P = 0.17); I 2(superscript) = 45.3%.

Figure 10 Proportion of subjects with global improvement – Short-term post-treatment

Figure 10 depicts Proportion of subjects with global improvement - Short-term post-treatment. On the left is a chart with three headings--Study Name, Acupuncture (with subhead n/N), and Placebo (with subhead n/M). On the right is another head, Relative risk and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, 0.1, 0.2, 0.5, 1, 2, 5, 10. A vertical line runs up from 1 with bullets on bars representing the numbers in the studies. On the upper left of that chart are the words Favors Acupuncture with an arrow pointing left, and on the upper right of the chart are the words Favors Placebo with an arrow pointing right. The results, left to right, are: Carlsson et al. 2001--16/34--2/16--3.77 (0.98, 14.4); Molsberger et al. 2002--36/49--23/49--1.57 (1.11, 2.20); Pooled--52/83--25/65--1.89 (0.93, 3.83). On the bottom left of the figure are the words: Heterogeneity: Chi 2(superscript) = 4.5, df = 1(P = 0.03): I 2(superscript) = 77.9%.

Figure 11 Proportion of subjects with global improvement – Intermediate-term post-treatment

Figure 11 depicts Proportion of subjects with global improvement - Intermediate-term post-treatment. On the left is a chart with three headings--Study Name, Acupuncture (with subhead n/N), and Placebo (with subhead n/M). On the right is another head, Relative risk and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, 0.1, 0.2, 0.5, 1, 2, 5, 10. A vertical line runs up from 1 with bullets on bars representing the numbers in the studies. On the upper right of that chart are the words Favors Acupuncture with an arrow pointing left, and on the upper right of the chart are the words Favors Placebo with an arrow pointing right. The results, left to right, are: Kerr et al. 2003--21/23--13/17--1.19 (0.89, 1.60); Haake et al. 2007--184/387--171/387--1.08 (0.92, 1.25); Pooled--205/410--184/404--1.10 (0.96, 1.26). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 1.4, df = 1 (P = 0.24); I 2(superscript) = 25.9%.

Figure 12 Functional disability (HFAQ score) – Immediate post-treatment

Figure 12 depicts Functional disability (HFAQ score) - Immediate post-treatment. On the left is a chart with three headings--Study Name, Acupuncture (with subhead n/N), and Placebo (with subhead n/M). On the right is another head, Difference in means and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -25.00, -12.50, 0.00, 12.50, 25.00. A vertical line runs up from 1 with bullets on bars representing the numbers in the studies. On the upper left of that chart are the words Favors Acupuncture with an arrow pointing left, and on the upper right of the chart are the words Favors Placebo with an arrow pointing right. The results, left to right, are: Haake et al. 2007--387--65.4 (22.9)--387--61.3 (22.7)--4.1 (0.89, 7.3); Brinkhaus et al. 2006--146--66.8 (18.3)--73--62.9 (20.3)--3.9 (-1.4, 9.2); Pooled--533--blank--460--4.0 (1.3, 6.8). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 0.004, df = 1 (P = 0.94); I 2(superscript) = 0.0%.

Figure 13 Functional disability (HFAQ score) – Intermediate post-treatment

Figure 13 depicts Functional disability (HFAQ score) - Intermediate post-treatment. On the left is a chart with three headings--Study Name, Acupuncture (with subhead n/N), and Placebo (with subhead n/M). On the right is another head, Difference in means and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -25.00, -12.50, 0.00, 12.50, 25.00. A vertical line runs up from 1 with bullets on bars representing the numbers in the studies. On the upper left of that chart are the words Favors Acupuncture with an arrow pointing left, and on the upper right of the chart are the words Favors Placebo with an arrow pointing right. The results, left to right, are: Haake et al. 2007--387--66.8 (23.1)--387--62.2 (23.0)--4.6 (1.4, 7.8); Brinkhaus et al. 2006--146--66.0 (20.1)--73--64.1 (22.9)--1.9 (-4.0, 7.8); Pooled--533--blank--460--blank--4.0 (1.1, 6.8). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 0.6, df = 1(P = 0.43); I 2(superscript) = 0.0%.

Acupuncture versus no treatment. There were four trials in which acupuncture was compared to no treatment in relation to low back pain intensity, back function, and overall quality of life.22,24,222,227 The results from these trials were consistent in showing a significant immediate, short, and intermediate-term post-treatment benefit of acupuncture compared to no treatment. For example, in three trials,22,24,227 subjects who received acupuncture experienced greater improvements in pain (VAS score: 0-10),22,24,227 pain disability index (PDI score),22 back function (Hannover Functional Ability Questionnaire, HFAQ),22,24 or quality of life (SF-36, physical health and pain subscale domains)22,24 compared with those in ‘no treatment‘ groups immediately or intermediate-term after the end of treatment. In the remaining one trial,222 there was statistically significantly better scores for pain (VAS scores) and mobility in the acupuncture (or electro-acupuncture) versus ‘no treatments’ group immediately or short-term after the treatment.222

The pooled estimate for short-term post-treatment pain intensity was statistically significant in favor of acupuncture (Figure 14; weighted mean difference on VAS score: -1.19, 95 percent CI: -2.17, -0.21).24,222,227

Figure 14 Pain intensity (VAS score) – Short-term post-treatment

Figure 14 depicts Pain intensity (VAS score) - Short-term post-treatment. On the left is a chart with three headings--Study Name, Acupuncture (with subheads N and Mean (SD)), and No Treatment (with subheads N and Mean (SD)). On the right is another head, Difference in means and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -10.00, -5.00, 0.00, 5.00, 10.00. A vertical line runs up from 1 with bullets on bars representing the numbers in the studies. On the upper right of that chart are the words Favors Acupuncture with an arrow pointing left, and on the upper right of the chart are the words Favors Placebo with an arrow pointing right. The results, left to right, are: Coan et al. 1980--25--2.8 (2.0)--25--4.7 (2.0)-- -1.85 (-2.96, -0.74); Thomas et al. 1994--1350--1.7 (1.2)--1244--2.4 (1.3)-- -0.68 (-0.78, -0.58); Witt et al. 1994--1350--1.7 (1.2)--1244--2.4 (1.3)-- -0.68 (-0.79, -0.58); Pooled--1405--blank--1279--blank-- -1.19 (-2.17, -0.21). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 4.99, df = 2(P = 0.08); I 2(superscript) = 59.9%.

Acupuncture versus other CAM treatment. Subjects who received manipulation,51,52,140 massage,29 or electro-acupuncture143 had significantly lower post-treatment pain intensity (VAS, MPQ scores) or disability (RDI, Oswestry, NDI scores) compared to subjects who received manual acupuncture. However, results from intermediate-term followup (3 months post-treatment) of one of these trials51,52 indicated numerically similar pain intensity in the manipulation group (median VAS score: 3.7) compared with acupuncture group (median VAS score: 3.9). The use of pain medication was significantly decreased in electro-acupuncture group compared to manual acupuncture group (six tablets versus 150 tablets, p < 0.001).143 In another trial,29 the use of pain medication did not differ in the acupuncture versus massage group (51.0 percent versus 47.0 percent, p > 0.05).

The meta-analysis comparing the effects of acupuncture and manipulation on immediate post-treatment pain intensity (Figure 15) indicated significant reductions in favor of manipulation over acupuncture (pooled mean difference in VAS score: 3.70, 95 percent CI: 1.5, 5.8).51,140 Although both trials51,140 reported immediate-term post-treatment disability data (Oswestry scores), they were not pooled due to obvious between-group baseline imbalance in this outcome scores.

Figure 15 Pain intensity (VAS score) – Immediate post-treatment

Figure 15 depicts Pain intensity (VAS score) - Immediate post-treatment. On the left is a chart with three headings--Study Name, Acupuncture (with subheads N and Mean (SD)), and Manipulation (with subheads N and Mean (SD)). On the right is another head, Difference in means and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -10.00, -5.00, 0.00, 5.00, 10.00. A vertical line runs up from 1 with bullets on bars representing the numbers in the studies. On the upper left of that chart are the words Favors Acupuncture with an arrow pointing left, and on the upper right of the chart are the words Favors Manipulation with an arrow pointing right. The results, left to right, are: Giles et al. 1999--16--5.1 (7.8)--32--2.5 (7.l0)--2.6 (-1.75, 6.9); Giles et al. 2003--33--7.0 (5.2)--35--3.0 (5.2)--4.0 (1.5, 6.5); Pooled--49--blank--67--blank--3.7 (1.5, 5.8). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 0.3, df = 1(P = 0.58); I 2(superscript) = 0.0%.

Acupuncture versus usual care. The effect of acupuncture compared to usual care (e.g., pain medication, antiinflammatory pills, general practitioner visits, exercise, and lifestyle modifications) was studied in three trials.37,226,228 In these trials subjects who received acupuncture improved in pain intensity, degree of disability, or quality of life compared to subjects in usual care groups.37,226,228

Acupuncture versus medication. The effect of acupuncture was compared to that of medication in four trials.51,140,214,216 In three studies51,52,140,216 acupuncture did not have a significantly different effect from that of medication in reducing immediate, or short term post-treatment pain intensity or disability (RMDQ, Oswestry score). In one of these trials51,52 acupuncture group achieved numerically better median Oswestry disability score than medication (13 versus 24) in intermediate term post treatment followup. This trial failed to report test results for between-group comparisons. In two meta-analyses (Figures 16-17) the immediate post-treatment effects of acupuncture and medication were not significantly different with respect to reductions in pain intensity (pooled mean difference in VAS score: 0.11, 95 percent CI: -1.42, 1.65)51,140,216,221 and disability (pooled mean difference in Oswestry score: -2.40, 95 percent CI: -12.20, 7.40).51,140

Figure 16 Pain intensity (VAS score) – Immediate post-treatment

Figure 16 depicts Pain intensity (VAS score) - Immediate post-treatment. On the left is a chart with three headings--Study Name, Acupuncture (with subheads N and Mean (SD)), and Medication (with subheads N and Mean (SD)). On the right is another head, Difference in means and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -10.00, -5.00, 0.00, 5.00, 10.00. A vertical line runs up from 1 with bullets on bars representing the numbers in the studies. On the upper right of that chart are the words Favors Acupuncture with an arrow pointing left, and on the upper right of the chart are the words Favors Medication with an arrow pointing right. The results, left to right, are: Giles et al. 1999--16--5.1 (7.8)--20--3.8 (4.8)--1.3 (-2.8, 5.4)--Giles et al. 2003--33--7.0 (5.2)--35--5 (3.7)--2.0 (-0.13, 41); Wang et al. 2004--23--2.6 (2.3)--17--3.3 (2.5)-- -0.76 (-2.3, 0.74); Itoh et al. 2009--7--4.8 (1.9)--7--5.8 (2.2)-- -1.1 (-3.2, 1.0); Pooled--79--blank--79--blank--0.11 (-1.42, 1.65). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 5.7, df = 3(P = 0.12); I 2(superscript) = 47.6%.

Figure 17 Disability (Oswestry score) – Immediate post-treatment

Figure 17 depicts Disability (Oswestry score) - Immediate post-treatment. On the left is a chart with three headings--Study Name, Acupuncture (with subheads N and Mean (SD)), and Medication (with subheads N and Mean (SD)). On the right is another head, Difference in means and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -25.00, -12.50, 0.00, 12.50, 25.00. A vertical line runs up from 1 with bullets on bars representing the numbers in the studies. On the upper left of that chart are the words Favors Acupuncture with an arrow pointing left, and on the upper right of the chart are the words Favors Medication with an arrow pointing right. The results, left to right, are: Giles et al. 1999--16--24.5 (26.6)--20--20.0 (21.5)--4.5 (-11.2, 20.2); Giles et al. 2003--33--26.0 (20.7)--35--32.0 (23.7)-- -6.0 (-16.l6, 4.6); Pooled--49--blank--55--blank-- -2.4 (12.2, 7.4). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 1.2, df = 1 (P = 0.27); I 2(superscript) = 15.3%.

Acupuncture versus other treatment. In three trials,53,163,216 the use of manual acupuncture was shown to be significantly superior to physiotherapy (consisted of light, electricity, and/ or heat therapy) in improving the degree of disability (Oswestry score)163 and similar to TENS in decreasing pain intensity (VAS scores).53,216 In one of these trials, the reduction in the use of pain medication was greater for the acupuncture versus TENS group (50.0 percent versus 33.0 percent, p < 0.05).53

The meta-analyses results from two trials in elderly (Figures 18-19) showed nonsignificant differences between acupuncture and TENS in reducing immediate (pooled mean difference in VAS score: 0.42, 95 percent CI: -3.24, 4.07)53,216 or short-term (pooled mean difference in VAS score: -0.15, 95 percent CI: -0.62, 0.33)53,216 post-treatment pain intensity.

Figure 18 Pain intensity (VAS score) – Immediate post-treatment

Figure 18 depicts Pain Intensity (VAS score) - Immediate post-treatment. On the left is a chart with three headings--Study Name, Acupuncture (with subheads N and Mean (SD)), and TENS (with subheads N and Mean (SD)). On the right is another head, Difference in means and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -10.00, -5.00, 0.00, 5.00, 10.00. A vertical line runs up from 1 with bullets on bars representing the numbers in the studies. On the upper left of that chart are the words Favors Acupuncture with an arrow pointing left, and on the upper right of the chart are the words Favors TENS with an arrow pointing right. The results, left to right, are: Grant et al. 1999--30--7.1 (6.6)--27--4.7 (4.4)--2.40 (-0.54, 5.34); Itoh et al. 2009--7--4.8 (1.9)--6--6.1 (2.4)-- -1.34 (-3.66, 0.98); Pooled--37--blank--33--blank--0.42 (-3.24, 4.07). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 3.8, df = 1(P = 0.05); I 2(superscript) = 74.0%.

Figure 19 Pain intensity (VAS score) – Short-term post-treatment

Figure 19 depicts Pain Intensity (VAS score) - Short-term post-treatment. On the left is a chart with three headings--Study Name, Acupuncture (with subheads N and Mean (SD)), and TENS (with subheads N and Mean (SD)). On the right is another head, Difference in means and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -10.00, -5.00, 0.00, 5.00, 10.00. A vertical line runs up from 1 with bullets on bars representing the numbers in the studies. On the upper left of that chart are the words Favors Acupuncture with an arrow pointing left, and on the upper right of the chart are the words Favors TENS with an arrow pointing right. The results, left to right, are: Grant et al. 1999--30--6.0 (6.5)--27--6.3 (6.0)--0.05 (-0.57, 0.47); Itoh et al. 2009--7004.3 (2.6)--6--5.8 (2.3)-- -060 (-1.l71, 0.52); Pooled--37--blank--33-- -0.15 (-0.62, 0.33). On the lower left of the figure are the words Homogeneity: Chi 2(superscript) = 0.8, df = 1(P = 0.38); I 2(superscript) = 0.0%.

In one trial,29 the post-treatment RMDQ scores did not differ between acupuncture and ‘self-care’ groups immediately (7.9 versus 8.8, p = 0.75) and also 1 year after the treatment (8.0 versus 6.4, p = 0.10). Another trial,216 demonstrated statistically significantly greater immediate post-treatment improvements for subjects treated with combination of acupuncture and TENS compared to those treated with acupuncture alone with respect to pain intensity (VAS: 36.6 ± 8.0 versus 37.4 ± 26.0, p < 0.008) and disability (RMDQ: 3.8 ± 0.8 versus 5.4 ± 3.4).

In two trials, subjects in electro-acupuncture groups had significantly lower post-treatment pain intensity scores (VAS, Numerical Rating Scale of Pain-NPRS)88,155 or increased trunk strength extension88 compared with subjects who received TENS88 or exercise sessions.155

Acupuncture + other treatment versus other treatment. There were five trials,99,198,200,216,226 in which both acupuncture and control (i.e., no treatment) groups were given either orthopaedic treatment,99 usual care (e.g., NSAIDs, muscle relaxants, Paracetamol, and back exercises),226 TENS,216 exercise,200or physiotherapy (method use was aimed to remove a muscle imbalance using the Bruegger-concept and special training of proper posture and motion)198 The addition of acupuncture to the above-mentioned therapies resulted in significant improvements in pain intensity (VAS mean scores) and disability (Pain Disability Index, Modified Roland Disability Score) compared to the control treatments (i.e., orthopaedic, usual care, or physiotherapy alone), immediately99,198,226 or short-term99 after the end of treatment. In one of the trials,226 the patterns of pain medication use did not differ significantly between the acupuncture and control groups (p = 0.07).

In one trial,200 subjects receiving a combination of electro-acupuncture and exercise had significantly improved pain intensity (NRS scores), disability (Aberdeen Low Back Pain scale), and spinal angular ROM (flexion and extension) compared with subjects receiving exercise alone at 3 months post-treatment. The use of analgesics was similar across the two groups (p = 0.385).200

In three meta-analyses (Figures 20-22) statistically significant differences in favor of combination of acupuncture with other treatment over other treatment were shown in the reduction of pain intensity immediately (pooled mean difference in VAS score: -1.65, 95 percent CI: -2.32, -0.98),99,198,200 short-term (pooled mean difference in VAS score: -2.23, 95 percent CI: -3.68, -0.79),99,200 and intermediate-term (pooled mean difference in VAS score: -1.55, 95 percent CI: -2.29, -0.81)198,200 after the end of treatment. In one meta-analysis based on two studies in elderly (Figure 23), there was no statistical significant difference in short-term post-treatment disability between the two intervention groups (pooled mean difference in RMDQ score: -3.15, 95 percent CI: -7.16, 0.87).216,226

Figure 20 Pain intensity (VAS score) – Immediate post-treatment

Figure 20 depicts Pain Intensity (VAS score) - Immediate post-treatment. On the left is a chart with three headings--Study Name, Acupuncture & Other (with subheads N and Mean (SD)), and Other (with subheads N and Mean (SD)). On the right is another head, Difference in means and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -10.00, -5.00, 0.00, 5.00, 10.00. A vertical line runs up from 1 with bullets on bars representing the numbers in the studies. On the upper left of that chart are the words Favors Acupuncture & Other with an arrow pointing left, and on the upper right of the chart are the words Favors Other with an arrow pointing right. The results, left to right, are: Liebling et al. 2001--35--2.1 (2.2)--39--4.4 (1.7)-- -2.3 (-3.19, -1.41); Molsberger et al. 2002--58--2.6 (2.1)--58--3.9 (2.1)-- -1.3 (-2.06, -0.54); Yeung et al. 2003--26--3.8 (2.1)--26--5.1 (2.2)-- -1.31 (-2.47, -0.15); Pooled--119--blank--123--blank-- -1.65 (-2.32, -0.98). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 3.2, df = 2 (P = 0.20); I 2(superscript) = 37.0%.

Figure 21 Pain intensity (VAS score) – Short-term post-treatment

Figure 21 depicts Pain Intensity (VAS score) - Short-term post-treatment. On the left is a chart with three headings--Study Name, Acupuncture & Other (with subheads N and Mean (SD)), and Other (with subheads N and Mean (SD)). On the right is another head, Difference in means and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -10.00, -5.00, 0.00, 5.00, 10.00. A vertical line runs up from 1 with bullets on bars representing the numbers in the studies. On the upper left of that chart are the words Favors Acupuncture & Other with an arrow pointing left, and on the upper right of the chart are the words Favors Other with an arrow pointing right. The results, left to right, are: Molsberger et al. 2002--47--2.3 (2)--36--5.2 (1.9)-- -2.9 (-3.75, -2.05); Yeung et al. 2003--26--3.8 (2.1)--26--5.2 (2.5)-- -1.42 (-2.67, -0.17); Pooled--73--blank--62--blank-- -2.23 (-3.68, -0.79). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 3.7, df = 1 (P = 0.05); I 2(superscript) = 72.8%.

Figure 22 Pain intensity (VAS score) – Intermediate-term post-treatment

Figure 22 depicts Pain Intensity (VAS score) - Intermediate-term post-treatment. On the left is a chart with three headings--Study Name, Acupuncture & Other (with subheads N and Mean (SD)), and Other (with subheads N and Mean (SD)). On the right is another head, Difference in means and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -10.00, -5.00, 0.00, 5.00, 10.00. A vertical line runs up from 1 with bullets on bars representing the numbers in the studies. On the upper left of that chart are the words Favors Acupuncture & Other with an arrow pointing left, and on the upper right of the chart are the words Favors Other with an arrow pointing right. The results, left to right, are: Leibling et al. 2001--33--3.1 (1.8)--31--4.4 (2)-- -1.40 (-2.33, -0.47); Yeung et al. 2003--26--3.5 (2.2)--26--5.3 (2.3)-- -1.81 (-3.03, -0.59); Pooled--59--blank--57--blank-- -1.55 (-2.29, -0.81). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 3.8, df = 1(P = 0.05); I 2(superscript) = 73.9%.

Figure 23 Disability (RMDQ score) – Short-term post-treatment

Figure 23 depicts Disability (RMDQ score) - Short-term post-treatment. On the left is a chart with three headings--Study Name, Acupuncture & Other (with subheads N and Mean (SD)), and Other (with subheads N and Mean (SD)). On the right is another head, Difference in means and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -10.00, -5.00, 0.00, 5.00, 10.00. A vertical line runs up from 1 with bullets on bars representing the numbers in the studies. On the upper left of that chart are the words Favors Acupuncture & Other with an arrow pointing left, and on the upper right of the chart are the words Favors Other with an arrow pointing right. The results, left to right, are: Meng et al. 2003--24--6.3 (4.4)--23--11.4 (4.8)-- -5.1 (-7.73, -2.47); Itoh et al. 2009--6--6.5 (1.6)--6--7.5 (3.6)-- -1.0 (-4.15, 2.15); Pooled--30--blank--29--blank-- -3.15 (-7.16, 0.87). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 3.8, df = 1 (P = 0.05); I 2(superscript) = 73.9%.

Acupuncture (type 1) versus acupuncture (type 2). In one trial,225 two modalities of needle insertion levels (muscle and overlying skin) were compared to electrical twitch-obtaining intramuscular stimulation (ETOIMS). Two weeks post-treatment, subjects in ETOIMS group had significantly lower mean VAS score (3.7 ± 1.9) compared with those in subjects in the two other groups of muscle and skin stimulation (4.2 ± 1.9 and 4.3 ± 2.3, respectively).

In two trials,136,204 different weekly frequencies of acupuncture were compared (high - five times versus low – twice). In one of these trials,136 post-treatment pain intensity (VAS scores) and degree of disability (RMDQ scores) were similar in groups of subjects randomized to high frequency (1 year VAS score: 1.41, 95 percent CI: 0.58, 2.24; 1 year RMDQ score: 13.10, 95 percent CI: 10.10, 16.11) versus low frequency (1 year VAS score: 1.35, 95 percent CI: 0.52, 2.18; 1 year RMDQ score: 12.33, 95 percent CI: 10.35, 14.31) at all points of post-treatment followup (5 weeks, 3 months, and 1 year).

The immediate and delayed acupuncture treatments were compared in three trials showing subjects to have similar post-treatment pain intensity (VAS score)22,24,227 or quality of life (SF-36: physical and mental components).24

In one trial,217 two groups of subjects receiving trigger point acupuncture versus tender point acupuncture were compared with respect to pain intensity (VAS) and disability (RMDQ) immediately after the treatment, showing significant improvements for both endpoints in the trigger point group compared to the tender point group.

In another trial,155 subjects in the electro-acupuncture and electrical heat acupuncture groups had similar pain intensity (NPRS: 2.43 ± 1.87 versus 2.27 ± 2.15, p > 0.05) and disability degree (RMDQ: 5.93 ± 3.79 versus 8.00 ± 5.66, p > 0.05).

In one trial,174 patients with chronic LBP responded better to electroacupuncture at local points than to acupuncture at local point in addition to weizhong point (curative effect rate: 96.1 percent versus 88.7 percent, P < 0.05) at similar needle retention duration (30 minutes).

Population with mixed duration of pain. A total of 44 trials with subjects having LBP of mixed duration were included in this section.110,121,134,138,146-151,153,154,157,158,161,164-166,170-173,175,177-185,187-195,209 The majority of these trials (39 studies) enrolled subjects with LBP due to specific causes (e.g., sciatica, disc protrusion, myofascial pain syndrome, lumbar transverse process syndrome, and spondylosis).134,138,146-151,154,157-159,161,164-166,170-173,177-185,187-195,232 Only five trials studied subjects with nonspecific LBP.110,121,153,175,209

Subjects with specific pain.

Acupuncture versus placebo. No relevant studies were identified.

Acupuncture versus other treatment. In one trial, the use of electro-acupuncture was more effective in reducing pain and increasing range of motion (straight leg raising) than manual therapy (manipulation or mobilization) or oral medication,164 In two other trials, the combinations of warming needle and moxibustion produced significantly better results than acupuncture alone.146,181

Acupuncture (type 1) versus acupuncture (type 2). There were 23 trials conducted 1predominantly in Chinese subjects with lumbar intervertebral disc protrusion,148-151,154,157,165,166,170,171,177-179,181-184,187,189,190,194,195 and myofascial pain,147which compared routine acupuncture (or electro-acupuncture) alone or in combination with other treatments (e.g., cupping, moxibustion, massage, traction, laser knife, hypodermic catgut embedding therapy, polarized light) to acupuncture of different modalities (e.g., abdomen-/body-acupuncture, round sharp/filiform needle, point-through-point, superficial needling, deep puncture), or needle-knife. Outcomes used in these studies were curative effect (definition varied across trials), VAS for pain intensity,154,157,165,166,195 and well being.170,171,177,178,182,184,187,189,190,194,195

In four trials,149,165,178,183 deep or point-through-point needling produced significantly greater therapeutic effect (i.e., being free of pain symptoms) compared with conventional acupuncture. The use of round sharp needle,194 contralateral needle,171 or along channel needle148 produced better therapeutic effect than conventional acupuncture. In two trials,179,187 abdominal acupuncture showed a significantly better effect compared with body acupuncture. Electro-acupuncture was worse than hypodermic catgut as shown in one study.182

Acupuncture versus other treatments. No relevant studies were identified.

Acupuncture versus medication. Elongated needling acupuncture,134warming needle acupuncture,146and electro-acupuncture138were reported to result in better curative effects than that of medication for patients with disc herniation. The medication used in these trials included oral Fenbid, Mobic, and Nimeisulide. For example the clinical cure rate for one study was 56.67 percent in acupuncture versus 26.67 percent in oral medication group.146 Similarly acupuncture at Gentong ankle points,154or huaisanzhen point,195was better than intramuscular injection of Aspirin-DL-lysine + saline,154or Bilinfen (0.9g) + physiological saline (2 ml)195 shown by higher curative effects. In one trial,138 the application of electro-acupuncture, compared to 7.5 mg/d mobic, significantly improved LBP pain, walking ability, raising straight leg, or muscle strength.

Acupuncture + other treatments versus the same other treatments. In two trials, scalp acupuncture in addition to traction193 or massage185 was shown to be more effective than traction or massage alone immediately after treatment. For example, in one study,193 the rates of clinically cured subjects in the combination and single treatment groups were 21.4 percent (acupuncture + traction) and 13.5 percent (traction alone), respectively.

The combination of acupuncture and traction,158 or manual therapy161,172,185 had a significantly better analgesic effect compared to traction or manual therapy alone in patients with disc herniation.158,161,172,185 In one of these studies, mean post-treatment VAS scores were statistically significantly different: 1.91 ± 0.93 (acupuncture + traction) versus 3.58 ± 1.52 (traction alone).158

Similarly, abdominal acupuncture in addition to body acupuncture and traction was also found to be more effective than body acupuncture or traction alone in patients with disc herniation (effective rate: 96.88 percent versus 89.29 percent, P < 0.05).180

In several other trials, acupuncture (or electro-acupuncture) in combination with another therapy (e.g., moxibustion, laser knife, massage) was shown to be more beneficial than acupuncture, laser knife, traction, or massage alone.150,158,172,177,193

Subjects with nonspecific pain.

Acupuncture versus placebo . No relevant studies were identified.

Acupuncture versus no treatment. No relevant studies were identified.

Acupuncture versus usual care. In one trial,110,112 a long-term post-treatment SF-36 bodily pain score was significantly improved in acupuncture group versus usual care group (mean between-group difference: 8.0, 95 percent CI: 2.8, 13.2). There were statistically nonsignificant differences in favor of acupuncture for disability (Oswestry score: -3.4, 95 percent CI: -7.8, 1.0) and pain intensity (MPQ: -0.2, 95 percent CI: -0.6, 0.1). There were no significant differences between the acupuncture and usual care groups in the long-term post-treatment mean hospital stay (days), general practitioner visits (3.78 ± 3.36 versus 4.26 ± 4.74), and outpatient visits (0.50 ± 1.62 versus 0.41 ± 1.95).112

Acupuncture (type 1) versus acupuncture (type 2). In one trial, 153 O^3^ acupoint injection had a significantly greater therapeutic effect compared to electro-acupuncture.

Acupuncture versus other treatments. In two trials, the effect of electro-acupuncture was compared to that of TENS121,209 for LBP treatment. In the first trial,209 electro-acupuncture and TENS did not significantly differ in pain relief. However, in the other trial,121 electro-acupuncture was associated with a significantly lower pain intensity (VAS scores) compared to TENS (mean between-group VAS score difference: 21, 95 percent CI: 4.12, 37,95).

Acupuncture versus medication. No relevant studies were identified.

Acupuncture + other treatments versus the same other treatments. No relevant studies were identified.

Population with unknown duration of pain. Nine trials were included in this sub-section.49,145,176,186,199,210,215,218,219 Six trials were restricted to subjects with nonspecific LBP49,145,199,210,215,218 and three trials enrolled patients with low back pain due to specific causes (sciatica, lumbar vertebrae hyperplasia, intervertebral disk herniation).176,186,219

Subjects with specific pain.

Acupuncture versus placebo. No relevant studies were identified.

Acupuncture versus no treatment. No relevant studies were identified.

Acupuncture versus another type/method of the same CAM. No relevant studies were identified.

Acupuncture versus other treatments. In one trial,186 the rate of cure (i.e., pain was absent) was significantly greater in electro-acupuncture (52.0 percent) versus medication group (42.0 percent). In another trial,176 the rate of cure (i.e., absence of pain) was significantly better in the electro-acupuncture versus TENS (80.0 percent versus 44.9 percent, p < 0.005).

Acupuncture versus medication. No relevant studies were identified.

Acupuncture (type 1) versus acupuncture (type 2). One trial,219 showed that subjects who received acupuncture at Kuesu point had immediate greater decrease in pain intensity score (PRS) than those who received acupuncture at nonKuesu point (PRS score: 5.30 versus 2.40, p = 0.003) and improvement in ROM extension (73.0 percent versus 40.0 percent). In one trial,186 the rate of cure (i.e., pain was absent) was significantly greater in electro-acupuncture (52.0 percent) versus acupuncture (40.0 percent).

Subjects with nonspecific pain.

Acupuncture versus placebo. In one trial, there were no significant differences in the proportions of subjects with improved pain (not specified) between the acupuncture versus placebo (sham-acupuncture).145 Either real needling210 or total body acupuncture218 was superior to sham needling in reducing LBP pain intensity immediately post treatment. For example, in one study,210 the mean pain intensity (VAS score) was 37.3 in acupuncture group and 64.1 in the placebo group.

Acupuncture versus no treatment. No relevant studies were identified.

Acupuncture (type 1) versus acupuncture (type 2). In two trials199,215 different methods of acupuncture were compared. In one trial,199 insertion of needles within the affected segment near typical acu-points showed to have better analgesic effect than insertion of the needles within the affected segment but far away from the acu-points (mean VAS score: 41.0 versus 83.0) In the other trial,215 needle retention for about 10 minutes was more effective than the removal immediately after the insertion.

Acupuncture versus other treatments. In one trial, there was no significant difference in the proportion of subjects with improved pain between subjects in dry needling acupuncture (61 percent improved) and subjects in acupressure + vapocoolant spray group (66 percent).49

Acupuncture versus medication. No relevant studies were identified.

Acupuncture + other treatments versus the same other treatments. In one trial,49 there was no significant difference in the proportion of subjects with improved pain between the dry needling acupuncture + Lidocaine injection (40 percent) and Lidocaine injection alone (45 percent) groups immediately after the end of treatment. In this trial, although the rate of pain improvement was numerically in favor of acupuncture (dry needling, or trigger point injection) compared to Lidocaine, the observed differences did not reach the statistical significance (61.0 percent versus 40.0 percent-45.0 percent, p > 0.05).

#### 2 Acupuncture for Treatment of Neck Pain

This section included 52 trials. Results of 10 trials were reported in multiple publications (Table 3).

Population/trial characteristics. The trials were conducted in Australia (three)51,140,234, Austria (two)17,235, Brazil (one)126, South Korea (one)46, China (20)229,236-254, Germany (four)77,80,106,131, Italy (one)255, Japan (two)256,257, Korea (one)45, New Zealand (one)258, Spain (one)259, Sweden (two)260,261, Switzerland (one)47, Taiwan (one)262, Turkey (one)263, United Kingdom (four)128,264-266, and United States (six).267-272

Most trials included adults whose age ranged from 18 to 60 years. One study recruited elderly adults only (60 years of age or older).45

The proportion of women was greater in 23 studies45,77,80,106,126,128,131,140,235,240,241,245,255-257,259,264-269,272, similar to that of men in 13 studies,51,229,234,236-239,242,244,247,249,251,252 smaller to that of men in two studies,258,270 and not reported in 10 studies.17,47,248,250,253,254,260-262,271 One study included only women.263

Racial composition of the study population was not reported in the majority of trials.

In total 8,515 participants with neck pain were randomized to acupuncture or control groups. Sample size for these trials ranged from 13^258^to 3,451 participants.131

Acupuncture alone (various methods of needling techniques) was used in 47 studies.45-47,51,77,79,80,106,126,128,140,229,234-246,248-263,265,266,268,269,271,272 Acupuncture was used in combination with other intervention in the experimental arm in seven studies.17,46,131,247,264,267,270 The control treatment for these trials was the same treatment included in the acupuncture arm (i.e. experimental treatment). Table 8 presents the control interventions in the included studies.

Table 8 Acupuncture for treatment of neck pain- Control interventions

Type of control group | Cause of Pain | N studies | Detail of Control intervention
Placebo/sham | Non Specific | 8 | Non penetrating needling at47,256,257 sham TENS at128, TENS (not at acu or not specified),258,259,266 needling at nonacu points47
Placebo/sham | Specific | 8 | Laser pen,17,77,80,106,263needling at nonacu-points,234,248superficial needling at260,261
No-treatment/ waiting list | Non Specific | 0 | NA
No-treatment/ waiting list | Specific | 1 | No treatment264
2- Active Controls
Exercise/physical activity | Non Specific | 0 | NA
Exercise/physical activity | Specific | 0 | NA
Cervical Collar (specific pain: whiplash injury) | Non Specific | 1 | Collar and analgesics17
Cervical Collar (specific pain: whiplash injury) | Specific | 0 | NA
Usual care | Non Specific | 2 | Medication, massage, recommended exercise ,267conventional treatment as needed,131
Usual care | Specific | 1 | Cervical collar, medication (Chlormezanon, Paracetamol) with or without laser17
Physiotherapy | Nonspecific | 1 | standard localized mobilization techniques, most commonly Maitland (rotation, postero-anterior oscillatory movement and longitudinal traction)265
Physiotherapy | Specific | 0 | NA
Traction | Nonspecific | 0 | NA
Traction | Specific | 2 | Traction alone229; traction and massage,252
Physical modalities | Nonspecific | 3 | TENS bilaterally (no details provided),272 Low level laser therapy (7, and -30 mW) on106laser acupuncture at classical47
Physical modalities | Specific | 1 | Laser at trigger points of upper trapezius muscle,263
Manual therapy | Nonspecific | 1 | Traction and massage252
Manual therapy | Specific | 4 | Spinal manipulation51,140,244, massage,245
Medication | Nonspecific | 2 | Rofecoxib/Vioxx followed by Paracetamol/Acetaminophen,51Tenoxican and Ranitidine,140
Medication | Specific | 4 | Lidocaine alone or in combination with Decadron,45,126NSAIDs,268, Diazepam260
Other methods of acupuncture | Nonspecific | 3 | Superficial vs. trigger point,256, needling along vs. across muscle fibers,240, with/out electrical stimulation,46,235
Other methods of acupuncture | Specific | 24 | Alternative techniques on acu-point needling (Shu)236Acu with thrusting, or twirling manipulation,80,237auricular needling at alternative oto-points,238long vs. short duration needle retention,239trigger point injection with Lidocaine,262, alternative ,46,241,242,253,254,268,269,271addition of auricular acu,255, acu with/out electrical stimulation,243,261,271Moxibustion in addition to electro-acupuncture,245,251, alternative needling method,249,250,252-254
Other active treatment (also in acupuncture group) | Nonspecific | 3 | Conventional care by GP,131,270medication, massage, recommended exercise267
Other active treatment (also in acupuncture group) | Specific | 6 | Stretching exercise ,264usual care,270spinal manipulation ,244cervical collar, medication and medication 17 manual therapy247massage246
Acupuncture in combination with another treatment (vs. acupuncture alone) | Nonspecific | 0 | NA
| Specific | 3 | Spinal manipulation,244cervical collar and medication,17spinal manipulation + massage,247

Acu=acupuncture; EMG=electromyography; GP=general practitioner care; NA= not applicable; NSAIDs= nonsteroid antiinflammatory drugs; TENS=transcutaneous electrical nerve stimulation

The number of treatments in Chinese studies varied from one to three courses, each course ranging 5-15 days in duration. The frequency of treatments in the majority of studies was once a day consecutively for the duration of the study course. The number of treatments ranged from < 10 sessions,234,237,247 10-20 sessions,241-243 up to 21-45 sessions.229,236,239,245,246,250,253 Two of the Chinese studies did not report the frequency or number of treatments.254,273

The frequency of treatment in the remaining studies reporting this information was a single treatment,80,238,240,248,260-262 one to two sessions per week (up to 12 treatments in total),79,131,235,244,255-257,263,265,267 two sessions per week (up to 18 treatments in total),47,51,77,106,128,140,249,258,259,266,268,272 three sessions per week (up to nine treatments in total),45,46,271 and four sessions per week (> 24 treatments in total).270

Risk of bias. The risk-of-bias graph for the trials included in this sub-section is presented in Figure 24. All trials were randomized. The adequate method of randomization and treatment allocation concealment was reported for about 26.0 percent and 15.0 percent of the trials, respectively. In 62.0 percent of the trials, the subjects’ baseline characteristics distribution across the treatment arms was similar (i.e., balanced). For at least 15.0 percent of the trials, it was unclear whether or not the subjects and assessors were blinded to the type of treatment. That subjects were blinded was reported for only 62.0 percent of the trials. Half of the trials reported acceptable drop-out rates (i.e., < 20.0 percent).9 Results based on intention-to-treat analysis were explicitly reported for 25.0 percent of the trials. The data for selected items of the risk of bias tool across the CAM interventions (acupuncture; spinal manipulation; spinal mobilization; combination of manipulation and mobilization; and massage therapy) is displayed in table 7.2 of Appendix G.

Figure 24 Risk of bias scores (%)

Figure 24 depicts the Risk of bias scores percents as a bar graph. On the left hand side are listed, vertically, Q1 through Q13. A horizontal solid black line represents Yes, a gray line, No, and a dotted line, Unclear. At the bottom, left to right, are the percentages 0%, 20%, 40%, 60% 80%, and 100%. Q1 is Yes 0 to about 30%, No between 30% and 40%, and Unclear, 40% to 100%. Q2 is Yes 0-about 20%, No about 20%-about 25%, and Unclear, about 25% to 100%. Q3 is Yes 0%- about 70%, No about 70% to 85%, and Unclear 85% to 100%. Q4 is Yes 0% to just under 20%, No just under 20% to over 60%, and Unclear about 60% to 100%. Q5 is Yes 0% to less than 10%, No less than 10% to just under 60%, and Unclear just under 60% to 100%. Q6 is Yes 0% to about 30%, Unclear about 30% to 100%. Q7 is Yes 0% to just under 40%, No just under 40% to about 40%, and Unclear about 40% to 100%. Q8 is Yes 0% to 30%, No 30% to just under 40%, and Unclear just under 40% to 100%. Q9 is Yes 0% to just under 60%, No just under 60% to about 90%, and Unclear about 90% to 100%. Q10 is Yes 0% to about 90%, No about 90% to about 95%, and Unclear about 95% to 100%. Q11 is Yes 0% to about 30%, No about 30% to about 45%, and Unclear about 45% to 100%. Q12 is Yes 0% to just under 60%, No just under 60% to about 75%, and Unclear from about 75% to 100%. Q13 is Yes 0% to about 10%, No about 10% to about 15%, and Unclear, about 15% to 100%.

Efficacy results. A summary of the key results is presented in Table 9. For further detail of the trials please see the evidence tables.(Appendix C, table 2.1 – table 2.8)

Table 9 Key results – Acupuncture treatment in patient with neck pain & cervicogenic headaches

Acupuncture therapy | Duration of pain | Cause of pain | Outcome | Risk-of-bias | Precision of the pooled estimate | Consistency | Directness | Finding | GRADE^ψ^
Acu vs. No Tx | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Acu vs. No Tx | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Acu vs. No Tx | Chronic/Mixed | S | - | - | - | - | - | - | Insufficient
Acu vs. No Tx | Chronic/Mixed | NS | - | - | - | - | - | - | Insufficient
Acu vs. No Tx | Unknown | S | SF-MPQ: B 264 | M | - | NA | Direct | = S-NS | Low
Acu vs. No Tx | Unknown | S | PPT: B264 | M | - | NA | Indirect | = S-NS | Low
Acu vs. No Tx | Unknown | S | SF-MPQ: C264 | M | - | NA | Direct | > SS | Low
Acu vs. No Tx | Unknown | S | PPT: C264 | M | - | NA | Indirect | = S-NS | Low
Acu vs. No Tx | Unknown | NS | - | - | - | - | - | - | Insufficient
Acu vs. PL | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Acu vs. PL | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Acu vs. PL | Chronic | S | VAS: B | M | Precise (2)^£^ 80, 234 | Yes | Direct | = S-NS | Moderate
Acu vs. PL | Chronic | NS | VAS: B | M | Precise (3)256,257,266 | No | Direct | = S-NS | Low
Acu vs. PL | Mixed | S | VAS: B263 | H | - | NA | Direct | = S-NS | Low
Acu vs. PL | Mixed | S | NHP: B, D263 | H | - | NA | Direct | = S-NS | Low
Acu vs. PL | Mixed | S | Use of analgesics (mean N of pills per day): B, D263 | H | - | NA | Direct | = S-NS | Low
Acu vs. PL | Mixed | S | ROM (flx, rot): B,D263 | H | - | NA | Indirect | = S-NS | Low
Acu vs. PL | Mixed | NS | - | - | - | - | - | - | Insufficient
Acu vs. PL | Unknown | S | % pts without symptoms: B 248 | H | - | NA | Direct | > SS | Low
Acu vs. PL | Unknown | NS | - | - | - | - | - | - | Insufficient
Acu vs. Med | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Acu vs. Med | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Acu vs. Med | Chronic | S | VAS: B 45,126,268 | H | - | No | Direct | => | Low
Acu vs. Med | Chronic | NS | VAS: B 51,260 | H | - | Yes | Direct | = S-NS | Low
Acu vs. Med | Mixed | S | - | - | - | - | - | - | Insufficient
Acu vs. Med | Mixed | NS | - | - | - | - | - | - | Insufficient
Acu vs. Med | Unknown | S | VAS: C249,262 | H | - | Yes | Direct | > SS | Low
Acu vs. Med | Unknown | NS | - | - | - | - | - | - | Insufficient
Acu vs. Mob | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Acu vs. Mob | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Acu vs. Mob | Chronic | S | - | - | - | - | - | - | Insufficient
Acu vs. Mob | Chronic | NS | VAS: B, D265 | M | - | NA | Direct | = S-NS | Low
Acu vs. Mob | Chronic | NS | NPQ: B, D265 | M | - | NA | Direct | = S-NS | Low
Acu vs. Mob | Chronic | NS | GHQ: B, D265 | M | - | NA | Direct | = S-NS | Low
Acu vs. Mob | Mixed/Unknown | S | - | - | - | - | - | - | Insufficient
Acu vs. Mob | Mixed/Unknown | NS | - | - | - | - | - | - | Insufficient
Acu vs. ST | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Acu vs. ST | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Acu vs. ST | Chronic | S | - | - | - | - | - | - | Insufficient
Acu vs. ST | Chronic | NS | NPQ: B267 | M | - | NA | Direct | = S-NS | Low
Acu vs. ST | Chronic | NS | % pts using medication: B267 | M | - | NA | Direct | > SS | Low
Acu vs. ST | Mixed/Unknown | S | - | - | - | - | - | - | Insufficient
Acu vs. ST | Mixed/Unknown | NS | - | - | - | - | - | - | Insufficient
Acu vs. Man | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Acu vs. Man | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Acu vs. Man | Chronic | S | VAS-C 244 | H | - | NA | Direct | = S-NS | Low
Acu vs. Man | Chronic | NS | VAS: C 51,140 | H | - | Yes | Direct | >< (NR) | Low
Acu vs. Man | Chronic | NS | VAS: D 51,52 | H | - | NA | Direct | = (NR) | Low
Acu vs. Man | Chronic | NS | Oswestry: C, D51,140 | H | - | Yes | Direct | < (NR) | Low
Acu vs. Man | Chronic | NS | NDI: C, D51,140 | H | - | Yes | Direct | < (NR) | Low
Acu vs. Man | Chronic | NS | SF-36: C, D 51 | H | - | NA | Direct | < (NR) | Low
Acu vs. Man | Mixed/Unknown | S | - | - | - | - | - | - | Insufficient
Acu vs. Man | Mixed/Unknown | NS | - | - | - | - | - | - | Insufficient
Acu vs. Ma | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Acu vs. Ma | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Acu vs. Ma | Chronic | S | ROM (flx, ext,rotation): C 77 | H | - | NA | Indirect | = S-NS | Low
Acu vs. Ma | Chronic | S | VAS: C 77 | H | - | NA | Direct | > SS | Low
Acu vs. Ma | Chronic | NS | - | - | - | - | - | - | Insufficient
Acu vs. Ma | Mixed/Unknown | S | - | - | - | - | - | - | Insufficient
Acu vs. Ma | Mixed/Unknown | NS | - | - | - | - | - | - | Insufficient
Acu vs. Laser Tx | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Acu vs. Laser Tx | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Acu vs. Laser Tx | Chronic | S | - | - | - | - | - | - | Insufficient
Acu vs. Laser Tx | Chronic | NS | VAS: C47,106 | L | - | - | Direct | = S-NS | Moderate
Acu vs. Laser Tx | Chronic | NS | ROM: C47,106 | L | - | - | Indirect | = S-NS | Low
Acu vs. Laser Tx | Mixed | S | VAS: B263 | H | - | NA | Direct | < SS | Low
Acu vs. Laser Tx | Mixed | S | ROM: B263 | H | - | NA | Indirect | < SS | Low
Acu vs. Laser Tx | Mixed | S | NHP: B263 | H | - | NA | Direct | < SS | Low
Acu vs. Laser Tx | Mixed | S | Use of analgesics (mean N of pills per day): B263 | H | - | NA | Direct | < SS | Low
Acu vs. Laser Tx | Mixed | S | VAS: D263 | H | - | NA | Direct | = S-NS | Low
Acu vs. Laser Tx | Mixed | S | ROM: D263 | H | - | NA | Indirect | = S-NS | Low
Acu vs. Laser Tx | Mixed | S | NHP: D263 | H | - | NA | Direct | = S-NS | Low
Acu vs. Laser Tx | Mixed | S | Use of analgesics (mean N of pills per day): D 263 | H | - | NA | Direct | = S-NS | Low
Acu vs. Laser Tx | Mixed | NS | - | - | - | - | - | - | Insufficient
Acu vs. Laser Tx | Unknown | S | - | - | - | - | - | - | Insufficient
Acu vs. Laser Tx | Unknown | NS | - | - | - | - | - | - | Insufficient
Acu vs. E-acu | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Acu vs. E-acu | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Acu vs. E-acu | Chronic | S | VAS: B 261 | H | - | NA | Direct | = S-NS | Low
Acu vs. E-acu | Chronic | NS | - | - | - | - | - | - | Insufficient
Acu vs. E-acu | Mixed | S | % pts who improved: B 243 | H | - | NA | Direct | < SS | Low
Acu vs. E-acu | Mixed | S | Time to effect (days): B 243 | H | - | NA | Direct | < SS | Low
Acu vs. E-acu | Mixed | NS | - | - | - | - | - | - | Insufficient
Acu vs. E-acu | Unknown | S | - | - | - | - | - | - | Insufficient
Acu vs. E-acu | Unknown | NS | - | - | - | - | - | - | Insufficient
Headache
Acu vs. TrP Injection | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Acu vs. TrP Injection | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Acu vs. TrP Injection | Chronic | S | VAS: B 126 | H | - | NA | Direct | = S-NS | Low
Acu vs. TrP Injection | Chronic | S | N of analgesics ingested weekly: C 126 | H | - | NA | Direct | = S-NS | Low
Acu vs. TrP Injection | Chronic | NS | - | - | - | - | - | - | Insufficient
Acu vs. TrP Injection | Mixed | S | - | - | - | - | - | - | Insufficient
Acu vs. TrP Injection | Mixed | NS | - | - | - | - | - | - | Insufficient
Acu vs. TrP Injection | Unknown | S | - | - | - | - | - | - | Insufficient
Acu vs. TrP Injection | Unknown | NS | - | - | - | - | - | - | Insufficient
Acu vs. PT | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Acu vs. PT | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Acu vs. PT | Chronic | S | - | - | - | - | - | - | Insufficient
Acu vs. PT | Chronic | NS | - | - | - | - | - | - | Insufficient
Acu vs. PT | Mixed | S | - | - | - | - | - | - | Insufficient
Acu vs. PT | Mixed | NS | - | - | - | - | - | - | Insufficient
Acu vs. PT | Unknown | S | - | - | - | - | - | - | Insufficient
Acu vs. PT | Unknown | NS | - | - | - | - | - | - | Insufficient

S=specific; NS=nonspecific; SS=statistically significant; S-NS=statistically nonsignificant; Man=manipulation; Acu=acupuncture; Ma=massage; Mob=mobilization; PL=placebo; Tx=treatment. Med=medication(s); Int=intervention; PT=physiotherapy; ST=standard therapy; E-acu=electro-acupuncture; MR=muscle relaxation; TENS= transcutaneous electrical nerve stimulation; Ex=exercise; TrP=trigger point; VAS=visual analog scale; RMDQ=Roland Morris Disability scale; NHP=Nottingham Health Profile; PPT= pressure pain threshold; HFAQ=Hanover functional ability questionnaire; MPQ=McGill pain questionnaire; ext=extension; flx=flexion; rot=rotation; PDI=pain disability index; min=minute(s); hr(s)=hour(s); L=low; M=medium; H=high; pt(s)=patient(s); SF=short-form; NPQ=neck pain questionnaire; GWBS=global well-being scale; SLR=straight leg raising; GPE= Global perceived effect; GHQ=general health questionnaire; NSAIDS=nonsteroidal antiinflammatory drugs; FTF=finger-to-floor; SF-PQ=short form pain questionnaire; PRI=pain rating index; PPI=present pain intensity; NA=not applicable

^ψ^ Grade (High, moderate, low, and insufficient)

^£^ Number of pooled trials

B = immediate post-treatment

C = short-term post-treatment

D = intermediate-term post-treatment

E = long-term post-treatment

H = high

L = low

M = medium

- No evidence

= Similar beneficial effect

> Favors treatment A over treatment B

< Favors treatment B over treatment A

><, =>, <= Inconsistent beneficial effect

Population with acute/subacute pain. This sub-section included only one trial conducted in subjects with specific neck pain (whiplash injuries).

Subjects with specific pain.

Acupuncture versus placebo. One trial17 evaluated the effects of acupuncture, laser acupuncture, and no treatment randomly given to patients with acute whiplash injuries. In all three groups, patients additionally received the combination of cervical collar and medication (450 mg Paracetamol and 100 mg Chlormezanon in a dose of three tablets a day). Patients who received acupuncture experienced numerically greater improvements in cervical ROM, shortened duration of acute pain and sick leave as compared to those in the other two treatment groups.

Acupuncture versus no treatment. No relevant studies were identified.

Acupuncture versus another type/method of the same CAM. No relevant studies were identified.

Acupuncture versus other treatments. No relevant studies were identified.

Acupuncture versus medication. No relevant studies were identified.

Acupuncture + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Acupuncture versus placebo. No relevant studies were identified.

Acupuncture versus no treatment. No relevant studies were identified.

Acupuncture versus another type/method of the same CAM. No relevant studies were identified.

Acupuncture versus other treatments. No relevant studies were identified.

Acupuncture versus medication. No relevant studies were identified.

Acupuncture + other treatments versus the same other treatments. No relevant studies were identified.

Population with chronic pain. A total of 31 trials evaluated the efficacy and/or harms of acupuncture in patients with chronic neck pain.45-47,51,77,80,106,126,128,131,140,234,235,241,244,251,254-261,265-268,270-272 Of these, 13 trials included patients with specific neck pain (e.g., myofascial pain syndrome, spinal canal stenosis, cervical disc disease)45,46,77,80,126,234,241,244,251,254,255,268,271 and the remaining 18 trials included patients with nonspecific neck pain.47,51,106,128,131,140,235,256-261,265-267,270,272

Subjects with specific pain.

Acupuncture versus placebo. In three trials, acupuncture77,234 or dry needling80 were similar to sham acupuncture234 or laser acupuncture77,80) for immediate/short-term post-treatment pain intensity (VAS, PPT),77,80,234 disability (NDI),234 and cervical ROM77,80,234 in patients with disc space narrowing/joint arthritis234 or myofascial pain syndrome77,80 For example, in one of these trials,80 post-treatment mean VAS values in dry needling and sham laser acupuncture groups were 29.2 (± 21.9) and 28.0 (± 19.4), respectively. The corresponding mean ROM values were 48.1 (± 7.0) versus 47.4 (± 7.1).80 In the same trial,80 distant acupuncture led to significantly lower pain intensity on VAS compared to sham (19.1 ± 16.1 versus 28.0 ± 19.4). No formal statistical test results for between-group comparisons were reported (e.g., p-value, 95 percent confidence interval).80

Results of one meta-analysis indicated no significant difference between acupuncture and placebo in the reduction of pain intensity, immediately after the end of treatment (pooled mean difference in VAS score: 0.27, 95 percent CI: -0.60, 1.13)80,234 (Figure 25).

Figure 25 Pain intensity (VAS Score) – Immediate post-treatment

Figure 25 depicts Pain Intensity (VAS score) - Immediate post-treatment. On the left is a chart with three headings--Study Name, Acupuncture (with subheads N and Mean (SD)), and Placebo (with subheads N and Mean (SD)). On the right is another head, Difference in means and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -10.00, -5.00, 0.00, 5.00, 10.00. A vertical line runs up from 1 with bullets on bars representing the numbers in the studies. On the upper left of that chart are the words Favors Acupuncture with an arrow pointing left, and on the upper right of the chart are the words Favors Placebo with an arrow pointing right. The results, left to right, are: Zhu et al. 2002--14--2.89 (2.8)--15--2.11 (2.2)--0.78 (-1.04, 2.60); Irnich et al. 2002--33--2.92 (2.2)--34--2.8 (1.9)--0.12 (-0.60, 1.13); Pooled--47--blank--49--blank--0.27 (-0.60, 1.13). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 0.4, df = 1 (P = 0.81); I 2(superscript) = 0.0%.

Acupuncture versus no treatment. No relevant studies were identified.

Acupuncture (type 1) versus acupuncture (type 2). In seven trials,46,80,241,251,254,268,271 different modes of acupuncture were evaluated. These included electro-acupuncture local points, 271 electro-acupuncture remote points,271 intramuscular stimulation (IMS)-acupuncture,46 turtle probing needling,241 local dry needling,80 acu-point sticking therapy,254 and relevant versus irrelevant points.268

In one trial,271 the use of electro–acupuncture (a local percutaneous electrical nerve stimulation) at local points was superior to acupuncture alone or electro–acupuncture at remote points in patients with cervical disc disease. The immediate post-treatment percent change on VAS for acupuncture versus local electro-acupuncture was 9.0 percent versus 38.0 percent; and the percent decrease in need for analgesics across these groups was 6.0 percent versus 37.0 percent. In another trial,80 distant acupuncture led to a significantly lower pain intensity on VAS (19.1 ± 16.1) compared with dry needling (29.2 ± 21.9) in patients with myofascial pain syndrome. There was a slight benefit of using Japanese acupuncture over irrelevant acupuncture (i.e., targeting nonspecific points) in immediate-/short-term post-treatment levels of pain intensity (SF-MPQ) in patients with myofascial pain syndrome (p < 0.05).268 In one trial,254 acupoint sticking therapy produced a greater effect rate ( percentage of patients with no symptoms, able to work, without relapse) compared to standard acupuncture (93.5 percent versus 72.4 percent, p < 0.05). In one trial, standard acupuncture did not differ from turtle-probing needling in producing immediate post-treatment analgesic effect (VAS pain post treatment mean 34.0 versus 36.0).241 Similarly, addition of IMS to dry needling in patient with myofascial pain syndrome did not have a significant effect on relieving pain when compared to dry needling alone (mean VAS post treatment: 4.54 ± 1.82 versus 4.69 ± 2.05).46 In one trail, there was either numerically or statistically significant greater benefit for the combination of acupuncture + Moxibustion, compared to acupuncture alone in improving immediate/short-term post-treatment pain intensity (NRS, VAS, FACES, PPT).251

Acupuncture versus other treatments. In two trials acupuncture was compared either to massage77 or spinal manipulation.244 In the first trial,77 which enrolled 177 patients with whiplash injuries and myofascial pain syndrome, acupuncture was shown to produce statistically significantly greater reduction in pain intensity (VAS score scale: 0-100) compared to massage in a short-term post-treatment period (mean change in VAS score from baseline: 24.22 versus 7.89, p = 0.005). The difference in efficacy with respect to pain intensity between acupuncture and massage was more pronounced in patients with myofascial pain syndrome or those with longer duration of disease (> 5 years). Although short-term post-treatment cervical ROM (flexion, extension, and rotation) in the acupuncture group was significantly greater than that in the massage group (mean degrees: 19.8 ± 38.0 versus 5.1 ± 22.2, p = 0.031), this difference between the two groups decreased at a later followup (mean ± SD: 8.9 ± 30.1 versus 5.5 ± 37.2, p = 0.81). No significant between-group difference was noted for PPT at any followup point.77 The combination of warm acupuncture and spinal manipulation had a better analgesic effect than acupuncture or spinal manipulation alone, in patients with neck pain due to spinal stenosis (mean VAS at short-term followup: 2.36 ± 2.8 versus 4.46 ± 3.11 versus 4.43 ± 2.51).244

Acupuncture versus medication. Three trials45,126,268 compared acupuncture to medications or medical injections. In two trials,45,126 subjects with myofascial pain syndrome and headache 126 or chronic neck pain with headache45 treated with acupuncture did not differ from those treated with injection of Lidocaine,45,126 Lidocaine plus corticoid,126 or Botulinum toxin126 for short-term post-treatment improvements in pain (Symptom Severity Index, VAS, Wong-Baker FACES pain scale)45,126 or cervical ROM (flexion, extension, tilting, and rotation).45 For example, in one of these trials,45 2 week post-treatment mean VAS values (scale: 0-10) for acupuncture and Lidocaine groups were 3.82 ± 2.47 and 3.46 ± 2.47, respectively (p > 0.05). The ROM flexion and extension values in the acupuncture group were 68.89 ± 11.19 and 67.72 ± 14.06, respectively. The corresponding ROM values in the Lidocaine injection group were 68.33 ± 14.78 and 65.00 ± 13.87. Although the number of ingested ibuprofen pills over 3 months numerically increased in all three intervention groups (needle, Lidocaine, Lidocaine plus corticoid, Botulinum toxin),126 there was no significant between-group difference at any time during the study periods (12 weeks: 32.93 ± 61.17 versus 35.28 ± 45.20 versus 17.85 ± 25.80 versus 15.53 ± 21.93, respectively). In one trial,268 relevant acupuncture was found to be modestly more effective than NSAIDs in reducing pain intensity (VAS, SF-MPQ) for myofascial pain syndrome.

Acupuncture + other treatments versus the same other treatments. Two trials,244,255 compared the efficacy and/or harms of acupuncture alone to combination of acupuncture with other treatments. These treatments included acupuncture + traction manipulation,244 and acupuncture + auriculotherapy.255

There was either numerically or statistically significant greater benefit for the combination of acupuncture with traction manipulation, compared to acupuncture alone in improving immediate/short-term post-treatment pain intensity (NRS, VAS, FACES, PPT).244 In one trial,255 amongst patients with myofascial pain syndrome, there was no statistically significant difference between short-/intermediate-term post-treatment effects of acupuncture alone versus acupuncture plus auricular acupuncture therapy on pain intensity (MPQ mean ± SD: 15.6 ± 11.4 versus 12.9 ± 13.9, p > 0.05; VAS pain mean ± SD: 18.9 ± 15.6 versus 21.0 ± 19.9, p > 0.05).

Subjects with nonspecific pain.

Acupuncture versus placebo. Standard acupuncture and placebo were compared in 10 trials,47,106,128,256-261,266 of which six found no significant difference between the two treatments in reducing post-treatment (immediate, short, or intermediate) pain (VAS, PPT, MPQ),47,256,257,260,261,266 or increasing cervical ROM.266 In most these trials placebo was represented by sham-acupuncture,47,256,257,260,261 and in one trial placebo was transcutaneous nerve stimulation (TENS).266

In contrast, in five trials,106,128,258-260 acupuncture was significantly better than placebo in improving pain intensity (VAS, NPQ, five-point scale)106,128,258-260 disability (NDI),128 the proportion of patients not taking analgesic medication,259 cervical mobility (active, passive; ROM),106,259 or quality of life (SF-36 physical component).128,259 The placebo treatments used in these trials were sham TENS at acupuncture points128, TENS (not at acu-points or not specified),258,259 or placebo-Diazepam.260

The meta-analysis showed no significant difference between acupuncture and placebo (sham-acupuncture) in reduction of immediate post-treatment pain intensity (pooled mean difference in VAS score: -0.24, 95 percent CI: -1.20, 0.73)256,257,266 (Figure 26). Trials comparing acupuncture to other types of placebos (e.g., TENS, drug)128,258-260 could not be pooled due to heterogeneity across outcomes, followup periods, or missing data.

Figure 26 Pain intensity (VAS Score) – Immediate post-treatment

Figure 26 depicts Pain Intensity (VAS score) - Immediate post-treatment. On the left is a chart with three headings--Study Name, Acupuncture (with subheads N and Mean (SD)), and Placebo (with subheads N and Mean (SD)). On the right is another head, Difference in means and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -10.00, -5.00, 0.00, 5.00, 10.00. A vertical line runs up from 1 with bullets on bars representing the numbers in the studies. On the upper left of that chart are the words Favors Acupuncture with an arrow pointing left, and on the upper right of the chart are the words Favors Placebo with an arrow pointing right. The results, left to right, are: Petrie et al. 1986--13--3.66 (2.3)--12--3.29 (1.9)--0.37 (-1.27, 2.01); Nabeta et al. 2002--17--4.33 (2.0)--17--4.68 (2.5)-- -0.35 (-1.88, 1.18); Itoh et al. 2007--8--4.59 (1.8)--7--5.46 (2.0)-- -0.87 (-2.77, 1.03); Pooled--38--blank--36--blank-- -2.24 (-1.20, 0.73). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 0.97, df = 2(P = 0.61); I 2(superscript) = 0.0%.

Acupuncture versus no treatment. No relevant studies were identified.

Acupuncture (type 1) versus acupuncture (type 2). In five trials, different modes of acupuncture were compared.47,235,240,256,261 The following techniques were compared as follows: standard acupuncture versus trigger point acupuncture,256 standard acupuncture versus electroacupuncture,235,261 classical acupuncture versus laser acupuncture,47 needle insertion across the muscle fibers versus needle insertion along the muscle fibers.240

Authors of one trial256 found standard acupuncture to be clinically less beneficial than trigger point acupuncture but similar to nontrigger acupuncture in decreasing pain intensity (VAS: 51.6 ± 22.0 versus 11.0 ± 9.3 versus 57.6 ± 18.0, respectively) and disability (NDI: 10.9 ± 6.6 versus 3.1 ± 3.2 versus 12.0 ± 4.5, respectively) immediately after treatment. In another trial,235 the addition of electro-acupuncture produced significantly greater improvements in VAS scores compared to standard acupuncture alone immediately and short-term after the treatment (p < 0.05). In one trial,47 laser acupuncture at classical acupuncture points and conventional needle acupuncture at classical acupuncture points did not differ in pain relief. There was no significant difference between standard acupuncture and nontraditional acupuncture (i.e., inconsistent with Chinese practice) as reported in this trial.47 In one trial,240 there were no significant differences between insertion of needles along the muscle fibers towards trigger points and insertion of needles across muscle fibers, in reducing motion related pain (mean VAS score), pain under pressure, or ROM. The standard acupuncture did not differ from electro-acupuncture in producing immediate post-treatment analgesic effect (VAS pain post-treatment mean ±SD: 1.8 ± 1.0 versus 1.4 ± 1.5, p > 0.05).in patients with cervical osteoarthritis.261

Acupuncture versus other treatments. Results from three trials indicated that there was no significant difference between standard acupuncture as compared to standard localized mobilization techniques,265 or laser therapy (three separate doses),47,106 in reducing immediate/short-term post-treatment pain intensity (VAS, PPT),106,265 disability (NPQ),265 cervical ROM (extension, flexion),106,265 or improving general health (General Health Questionnaire 28).265 In one of two trials,51,140 acupuncture was better than manipulation in reducing pain intensity (VAS score: percentage decrease) short-term after the end of 9 weeks treatment (50.0 percent versus 42.0 percent).51 In the same trial,51,52 intermediate-term followup results (3 months post-treatment) indicated numerically similar pain intensity in the acupuncture group compared with manipulation group (VAS median scores: 2.5 versus 2.8). This trial failed to report test results for between-group comparisons. In the other trial,140 immediate post-treatment reduction in pain intensity (VAS: 33.0 percent) and neck disability (NDI score: 25.0 percent) was significantly greater in manipulation versus acupuncture group.

Acupuncture versus medication. Acupuncture and medication (e.g., NSAIDs, analgesics) were compared in three trials.51,140,260

In the first trial,260 with a limited statistical power, there was no statistically significant difference in pain VAS scores immediately post-treatment between the acupuncture and Diazepam (orally, five mg) groups of subjects with osteoarthritis. The second trial140 did not report between group differences in pain and disability scores. Calculation of median effect size suggested no difference in pain and disability at immediate post-treatment followup. The proportion of patients crossing over to another intervention was statistically significantly different (p = 0.002) across the three interventions: manipulation (22.2 percent), acupuncture (60.0 percent), and NSAIDs (62.0 percent).140 In the third trial,51 acupuncture group appeared to have a significantly improved neck pain (mean VAS scores) compared to medication group immediately post intervention. For example, mean VAS ± SD scores in the acupuncture and medication groups were 4.0 ± 4.4 and. 6.0 ± 4.4, respectively.51 Intermediate-term followup results (3 months post-treatment) from one of these trials51,52 showed numerically better pain intensity for acupuncture compared to medication (VAS median scores: 2.5 versus 4.7). This trial failed to report test results for between-group comparisons.

Acupuncture + other treatments versus the same other treatments. This sub-section included three trials.131,267,270 In two trials,131,267 acupuncture was added to either general practitioner care 267 or conventional care,131 and in one trial,270 acupuncture and waiting list control groups were compared.

In the first trial,131 treatment with acupuncture added to routine – conventional care was shown to produce a significantly reduced pain intensity (VAS scores), disability (Neck Pain and Disability scale; NPAD), and physical functioning scores (SF-36) compared to treatment with routine care alone immediately after the end of treatment. The between-group differences for SF-36 (physical functioning: 1.3, 95 percent CI: 0.1, 2.5) and NPAD (2.9, 95 percent CI: 0.8, 4.9) were statistically significant at 3 months post-treatment. In the other trial,267 acupuncture was added to general practice care and showed no difference in pain and disability (NPQ) compared to general practice care alone immediately post-treatment. The proportion of patients reporting the use of medication in the acupuncture group decreased from baseline to 3 months (from 40.0 percent to 11.1 percent) as opposed to the general practitioner group in which it did not change over the same period of time (from 43.0 percent to 42.0 percent). In the third trial,270 there was no significant difference in the mean pain scores (3.6 versus 5.4) or mean number of pills taken per week (7.5 versus 8.7) between the combined acupuncture and other treatment alone at 12 weeks post-randomization.

Population with mixed duration of pain. A total of 14 trials evaluating the efficacy and/or harms of acupuncture in patients with neck pain of mixed duration were included in this section.229,236-238,240,242,243,245-247,252,253,263,269 All except for one trial240 enrolled patients with specific neck pain (e.g., spondylosis, spondylopathy, myofascial pain syndrome, whiplash injuries). Please, see the results of two trials246,247 in the Massage section, Mixed Duration Neck Pain sub-sections.

Subjects with specific pain.

Acupuncture versus placebo. In one trial,263 60 patients with myofascial pain syndrome had similar post-treatment pain intensity (VAS, PPT), cervical ROM, functional status (Nottingham Health Profile - pain scale), and the use of analgesics in the acupuncture versus placebo (laser pen) group and the observed differences were statistically nonsignificant at all followup time points.

Acupuncture versus no treatment. No relevant studies were identified.

Acupuncture (type 1) versus acupuncture (type 2). In six trials, acupuncture was compared to electro-acupuncture,243 deep needling,236 lifting-thrusting needling,237 penetrative needling,238 needle-knife,242 or centro-square needling.252 One additional trial compared most tender points and nonselective points.269

Two trials demonstrated that in patients with spondylopathy or spondylosis, the use of electro-acupuncture had significantly better therapeutic effect (percentage of the relative mean score change between baseline and post-treatment followup) compared to routine acupuncture.243Different modalities of acupuncture were compared in six Chinese trials.236-238,242,252,269 The results indicated numerically or statistically significantly better therapeutic effects (defined differently across the trials as dichotomous outcome) of deep needling,236 lifting-thrusting needling,237 penetrative needling,238 needle-knife,242 or centro-square needling252 compared with routine acupuncture (at Jiaji, Cuchi points). In one trial,269 there was a greater proportion of patients with myofascial pain syndrome having pain relief (‘yes’ or ‘no’ answer) amongst those needled at most tender points as opposed to those needled at nonselective points.

Acupuncture versus other treatments. In three trials, acupuncture was compared to laser, 263 traction-massage,252 or traction.229 In the first trial,263 patients immediately after being treated with laser therapy, had significantly improved pain intensity (VAS: 2.05 ± 1.43 versus 3.71 ± 2.33, p < 0.05; PPT: 3.99 ± 1.22 versus 2.51 ± 1.57, p < 0.001), cervical ROM (flexion: 64.16 ± 9.25 versus 59.67 ± 10.52, p < 0.001; extension: 81.95 ± 10.84 versus 72.86 ± 12.18, p < 0.001), and functional status (Nottingham Health Profile - pain scale: 13.51 ± 14.07 versus 33.86 ± 28.37, p < 0.001) compared to those treated with acupuncture. However, 5 months post-treatment, the observed between-group differences in the above mentioned outcomes got numerically diminished and were no longer statistically significant (p > 0.05). Although the use of analgesics immediately after the treatment was significantly lower in the laser therapy versus acupuncture group (0.85 ± 1.53 versus 3.62 ± 4.41, p < 0.05), 5 months later the use of analgesics between the two groups differed no more (1.41 ± 3.43 versus 2.53 ± 2.74, p > 0.05).263 In the second trial,252 acupuncture was shown to have a greater effect on well being (no numerical data reported) compared to traction-massage in patients with spondylosis. In one trial,229 it was demonstrated that in patients with spondylopathy or spondylosis, the use of electro-acupuncture had significantly better therapeutic effect (percentage of the relative mean score change between baseline and post-treatment followup) compared to traction.

Acupuncture versus medication. No relevant studies were identified.

Acupuncture + other treatments versus other treatments. In one small Chinese trial,245 the combination of electro-acupuncture and acupuncture did not differ from electro-acupuncture alone in producing curative therapeutic effect (percentage of patients with no symptoms who were able to work without relapse).

Subjects with nonspecific pain.

Acupuncture versus placebo. No relevant studies were identified.

Acupuncture versus no treatment. No relevant studies were identified.

Acupuncture (type 1) versus acupuncture (type 2). In one trial of 47 patients,240 two modalities of Fu’s subcutaneous needling were compared, needling along the local muscle fibers pointed to the myofascial trigger points, and needling across the local muscle fibers pointed to the myofascial trigger points.

Although post-treatment pain intensity (VAS; motion-related, pain under pressure) and cervical ROM improved significantly in both groups, there were statistically nonsignificant differences with respect to pain intensity (motion-related: 3.59 versus 2.76, p = 0.95; pain under pressure: 3.82 versus 3.28, p = 0.38) and cervical ROM (flexion, extension, and rotation: 1.36 versus 1.12, p = 0.38) between the two groups of patients.

Acupuncture versus other treatments. No relevant studies were identified.

Acupuncture versus medication. No relevant studies were identified.

Acupuncture + other treatments versus the same other treatments. No relevant studies were identified.

Population with unknown duration of pain. A total of six trials were included in this sub-section.239,248-250,262,264

Subjects with specific pain.

Acupuncture versus placebo. In one trial,248 acupuncture was shown to be associated with a significantly greater effective rate (percentage of patients with no symptoms or relapse: 75.5 percent versus 52.8 percent, p < 0.05) compared to placebo (needling at non acupuncture points) right after the treatment.

Acupuncture versus no treatment. In one trial,264 acupuncture was shown to be significantly more effective than no treatment in improving pain intensity (short form MPQ) and PPT shortly after the end of treatment.

Acupuncture (type 1) versus acupuncture (type 2). In three Chinese trials,239,249,250 different modalities of acupuncture were compared. These included needle pricking,249 long-time needle retention,239 or point-through-point needling.250 In all three trials the short-term post-treatment results indicated numerically or statistically significantly better therapeutic effects (defined differently across the trials as dichotomous outcome) of needle pricking,249 long-time needle retention,239 or point-through-point needling250 compared to routine acupuncture.

Acupuncture versus other treatments. In three trials,249,262,264 acupuncture was shown to be significantly more effective than injection of Lidocaine,249,262 or exercise264 in improving pain intensity (VAS, SF-MPQ, PPT) and/or disability (neck pain disability VAS) shortly after the end of treatment.

Acupuncture versus medication. No relevant studies were identified.

Acupuncture + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Acupuncture versus placebo. No relevant studies were identified.

Acupuncture versus no treatment. No relevant studies were identified.

Acupuncture versus another type/method of the same CAM. No relevant studies were identified.

Acupuncture versus other treatments. No relevant studies were identified.

Acupuncture versus medication. No relevant studies were identified.

Acupuncture + other treatments versus the same other treatments. No relevant studies were identified.

#### 3 Spinal Manipulation for Treatment of Low Back Pain

We included 28 studies using manipulation alone and six studies using manipulation plus other treatments.31,57,123,274-276 Note that one trial277 reported results for subjects with acute and chronic pain separately, therefore this trial appears in two sub-sections of acute and chronic pain. Results of nine trials were reported in multiple publications (Table 3).

Population/trial characteristics. The studies were conducted in Australia (three),51,140,274 Bulgaria (one),20 Canada (four),278-281 China (two),275,282 Denmark (three),276,283,284 Egypt (one),104 Italy (one),277 South Africa (one),285 UK (five),123,230,286-288 and United States (13).31,55,57,101,119,289-296

The proportion of men and women was similar in 19 studies (40 percent to <60 percent).20,31,51,55,57,119,123,140,275-279,285,288,289,291,295,296 In five studies, there was a greater proportion of men (> 60 percent)101,280,281,284,290 and in five studies women were the majority (> 60 percent).274,282,283,286,293 For the remaining studies, this information was not reported.104,230,287,292,294

The included studies consisted of adults aged 18 years or older. The racial composition or ethnicity was reported for only four studies.123,275,289,290 In three trials, the majority of subjects were Caucasians.123,289,290 This information was not reported for the remaining trials.

In total 15,969 participants with LBP were randomized to manipulation (alone or combined with other treatment) or control groups. One large RCT accounted for 11,128 patients during its 11 years of recruitment between 1986 and 2007.^275^ Table 10 presents the control interventions in the included studies.

Table 10 Spinal Manipulation for Treatment of low back pain- Control Interventions

Type of control group | Cause of Pain | N studies | Detail of Control intervention
1 – Inactive treatments
Placebo/sham | Non Specific | 9 | Sham adjustment + placebo medication,57sham adjustment and muscle relaxation ,57sham adjustment,119,293light physical contact at lumbar spine,291sham mobilization ,20similar palpation and positioning as manipulation group + nontherapeutic massage to site unrelated to pain,104no physical contact281simulated short wave ,284placebo gel,277
Placebo/sham | Specific | 0 | NA
No-treatment/ waiting list/ bed rest | Non Specific | 4 | No treatment,288,288,291bed rest,277
No-treatment/ waiting list/ bed rest | Specific | 0 | NA
2- Active treatments
Exercise/physical activity | Non Specific | 1 | low-stress aerobic and lumbar spine strengthening,123
Exercise/physical activity | Specific | 0 | NA
Usual care | Non Specific | 3 | Base on UK National Acute Back Pain Guidelines,123analgesic medication prescription, local analgesic-anesthetic injections(also bed rest and or physiotherapy including ultrasound and diathermy and ergonomic advice),283physician consultation, medication ,296
Usual care | Specific | 0 | NA
Corset | Non Specific | 1 | Lumbo-sacral corset,101
Corset | Specific
Education | Non Specific | 4 | Back school program,280,290education booklet,278educational material, and presentation by therapist,119
Education | Specific
Physiotherapy | Nonspecific | 2 | McKenzie approach,278massage, electrotherapy, infrared,277
Physiotherapy | Specific | 0 | NA
Physical modalities | Nonspecific | 3 | TENS,101ultrasound,286Infrared lamp over the most painful area of the low back,230
Physical modalities | Specific | 0 | NA
Other Manual therapy | Nonspecific | 7 | Myofascial therapy,290massage ,101,292,295post isometric relaxation,20spinal mobilization55,296
Other Manual therapy | Specific | 0 | NA
Medication | Nonspecific | 5 | Paracetamol/Acetaminophen,51Tenoxican and Ranitidine,140medication and bed rest,104Naprosyn,287Diclophenac,277
Medication | Specific | 0 | NA
Other methods of manipulation | Nonspecific | 3 | Not described,282full spine adjustment, or combination of full spin and cervical adjustment,294application of activator adjusting instrument,285
Other methods of manipulation | Specific | 0 | NA
Other active treatment (also in manipulation group) | Nonspecific | 4 | Exercise,31,123,274,276
Other active treatment (also in manipulation group) | Specific | 1 | Lumbar traction and physical modalities,275
Spinal manipulation in combination with another treatment (vs. acupuncture alone) | Nonspecific | 2 | Physical modalities (heat/ ice, ultrasound, electrotherapy, massage and/or trigger point therapy) in 3, 6, 9, or 12 treatment sessions,289myofascial therapy,290
Spinal manipulation in combination with another treatment (vs. acupuncture alone) | Specific | 0 | NA

GP=general practitioner care; NA= not applicable; TENS=transcutaneous electrical nerve stimulation; UK=United Kingdom

The treatment in studies was administered with the following frequency: single treatment,279,281,291,295,297 less than once a week for total duration of 12 weeks,95 once a week for a total duration of 1 to 3 weeks ,288,290one-two sessions per week for a duration to 12 weeks,39,123,286,298 twice a week for duration of to 12 weeks,51,274,282,285,289 three or four times per week for a duration of 2-3 weeks,20,57,101,104,230,284 and four to seven times per week for a duration of 2-6 weeks.119,140,275,277 In one trial, the frequency of treatment administration varied.295 The information regarding the frequency or duration of treatment was not reported for two trials.31,294

Risk of bias. The risk-of-bias graph for the trials included in this sub-section is presented in Figure 27. All trials were randomized. One trial, was reported in an abstract format and was not included in the assessment of risk of bias.287 The adequate method of randomization and treatment allocation concealment was reported for 18.0 percent and 11.0 percent of the trials, respectively. Up to 61.0 percent of the trials reported that distribution of the subjects’ baseline characteristics across the treatment arms was similar. The subjects were reported to be blinded in only 11.0 percent of the trials. About 36.0 percent of the trials reported acceptable drop-out rate. Results based on intention-to-treat analysis were explicitly reported for 25.0 percent of the trials. The data for selected items of the risk of bias tool across the CAM interventions (acupuncture; spinal manipulation; spinal mobilization; combination of manipulation and mobilization; and massage therapy) is displayed in table 7.1 of Appendix G.

Figure 27 Risk of bias scores (%)

Figure 27 depicts the Risk of bias scores percents as a bar graph. On the left hand side are listed, vertically, Q1 through Q13. A horizontal solid black line represents Yes, a gray line, No, and a dotted line, Unclear. At the bottom, left to right, are the percentages 0%, 20%, 40%, 60% 80%, and 100%. Q1 is Yes 0 to about 20%, No between 20% and 30%, and Unclear, 40% to 100%. Q2 is Yes 0 to about 15%, No about 15% to about 30%, and Unclear, about 30% to 100%. Q3 is Yes 0% to about 60%, No about 60% to 80%, and Unclear 80% to 100%. Q4 is Yes 0% to about 10%, No about 10% to 70%, and Unclear about 70% to 100%. Q5 is Yes 0% to about 70%, and Unclear about 70% to 100%. Q6 is Yes 0% to about 40%, No about 40% to 50%, Unclear 50% to 100%. Q7 is Yes 0% to 30%, No 30% to about 35%, and Unclear about 35% to 100%. Q8 is Yes 0% to 30%, No 30% to 50%, and Unclear 50% to 100%. Q9 is Yes 0% to just under 40%, No just under 40% to just under 60%, and Unclear just under 60% to 100%. Q10 is Yes 0% to 80%, Unclear 80% to 100%. Q11 is Yes 0% to over 25%, No over 25% to about 30%, and Unclear about 30% to 100%. Q12 is Yes 0% to about 65%, No about 65% to about 90%, and Unclear from about 90 to 100%. Q13 is Yes 0% to about 15%, Unclear about 15% to 100%.

Efficacy results. A summary of the key results is presented in Table 11. For further detail of the trials please see the evidence tables. (Appendix C, table 1.9 – table 1.16)

Table 11 Key results –Spinal manipulation therapy for low back pain

CAM therapy | Duration of pain | Cause of pain | Outcome | Risk-of-bias | Precision of the pooled estimate | Consistency | Directness | Finding | GRADE^ψ^
Man vs. No Tx | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man vs. No Tx | Acute/subacute | NS | VAS: B291 | M | - | NA | Direct | > SS | Low
Man vs. No Tx | Chronic | S | - | - | - | - | - | - | Insufficient
Man vs. No Tx | Chronic | NS | ROM: B281 | H | - | NA | Indirect | = S-NS | Low
Man vs. No Tx | Mixed | S | - | - | - | - | - | - | Insufficient
Man vs. No Tx | Mixed | NS | VAS: B, C 288 | H | - | NA | Direct | > NR | Low
Man vs. No Tx | Unknown | S | - | - | - | - | - | - | Insufficient
Man vs. No Tx | Unknown | NS | - | - | - | - | - | - | Insufficient
Man vs. PL | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man vs. PL | Acute/subacute | NS | VAS: B, C20,57,277,284,291 | M | - | Yes | Direct | > SS | Moderate
Man vs. PL | Acute/subacute | NS | Oswestry: B,C57 | M | - | NA | Direct | = S-NS | Low
Man vs. PL | Acute/subacute | NS | ROM (schober’s test): B, C20,57,284 | M | - | No | Indirect | => | Low
Man vs. PL | Acute/subacute | NS | Number of analgesics ingested weekly: B57 | M | - | NA | Indirect | = S-NS | Low
Man vs. PL | Chronic | S | - | - | - | - | - | - | Insufficient
Man vs. PL | Chronic | NS | VAS: B, C119,277,293 | M | - | No | Direct | => | Low
Man vs. PL | Chronic | NS | Oswestry: C119 | M | - | NA | Direct | = S-NS | Low
Man vs. PL | Mixed | S | - | - | - | - | - | - | Insufficient
Man vs. PL | Mixed | NS | VAS: B104 | H | - | NA | Direct | > NR | Low
Man vs. PL | Unknown | S | - | - | - | - | - | - | Insufficient
Man vs. PL | Unknown | NS | - | - | - | - | - | - | Insufficient
Man^**^M vs. PL | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man^**^M vs. PL | Acute/subacute | NS | VAS: B56 | M | - | NA | Direct | = S-NS | Low
Man^**^M vs. PL | Acute/subacute | NS | RMDQ: B56 | M | - | NA | Direct | = S-NS | Low
Man^**^M vs. PL | Acute/subacute | NS | SF-36^56^ | M | - | NA | Direct | = S-NS | Low
Man^**^M vs. PL | Chronic/Mixed | S | - | - | - | - | - | - | Insufficient
Man^**^M vs. PL | Chronic/Mixed | NS | - | - | - | - | - | - | Insufficient
Man^**^M vs. PL | Unknown | S | - | - | - | - | - | - | Insufficient
Man^**^M vs. PL | Unknown | NS | ROM (flx, ext, SLR): B, C, D108 | H | - | NA | Indirect | = S-NS | Low
Man vs. Med | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man vs. Med | Acute/subacute | NS | VAS: B, C287 | NA^#^ | - | NA | Direct | = S-NS | Low
Man vs. Med | Acute/subacute | NS | RMDQ: B, C287 | NA^#^ | - | NA | Direct | = S-NS | Low
Man vs. Med | Acute/subacute | NS | VAS: D277 | H | - | NA | Direct | = S-NS | Low
Man vs. Med | Chronic | S | - | - | - | - | - | - | Insufficient
Man vs. Med | Chronic | NS | VAS: B51,140 | H | - | Yes | Direct | > SS | Low
Man vs. Med | Chronic | NS | VAS: C, D277 | H | - | NA | Direct | = S-NS | Low
Man vs. Med | Chronic | NS | Oswestry: B51,140 | H | - | Yes | Direct | > SS | Low
Man vs. Med | Mixed | S | - | - | - | - | - | - | Insufficient
Man vs. Med | Mixed | NS | % pain-free pts: B, C283 | H | - | NA | Indirect | = S-NS | Low
Man vs. Med | Unknown | S | - | - | - | - | - | - | Insufficient
Man vs. Med | Unknown | NS | - | - | - | - | - | - | Insufficient
Man vs. PT | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man vs. PT | Acute/subacute | NS | VAS: C277 | H | - | NA | Direct | > SS | Low
Man vs. PT | Chronic | S | - | - | - | - | - | - | Insufficient
Man vs. PT | Chronic | NS | VAS: C277 | H | - | NA | Direct | < SS | Low
Man vs. PT | Mixed | S | - | - | - | - | - | - | Insufficient
Man vs. PT | Mixed | NS | VAS: B, C278 | H | - | NA | Direct | = S-NS | Low
Man vs. PT | Mixed | NS | RMDQ: B, C278 | H | - | NA | Direct | = S-NS | Low
Man vs. PT | Unknown | S | - | - | - | - | - | - | Insufficient
Man vs. PT | Unknown | NS | - | - | - | - | - | - | Insufficient
Man^**^ vs. PT | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. PT | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Man^**^ vs. PT | Chronic | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. PT | Chronic | NS | - | - | - | - | - | - | Insufficient
Man^**^ vs. PT | Mixed | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. PT | Mixed | NS | VAS: B, C84 | M | - | NA | Direct | > SS | Low
Man^**^ vs. PT | Mixed | NS | Physical functioning (10-point scale): B, C84 | M | - | NA | Direct | > SS | Low
Man^**^ vs. PT | Mixed | NS | GPE: B, C84 | M | - | NA | Direct | = S-NS | Low
Man^**^ vs. PT | Unknown | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. PT | Unknown | NS | - | - | - | - | - | - | Insufficient
Man vs. ST | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man vs. ST | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Man vs. ST | Chronic | S | - | - | - | - | - | - | Insufficient
Man vs. ST | Chronic | NS | - | - | - | - | - | - | Insufficient
Man vs. ST | Mixed | S
Man vs. ST | Mixed | NS | VAS: B, C296 | L | - | NA | Direct | = S-NS | Low
Man vs. ST | Mixed | NS | RMDQ: B, C296 | L | - | NA | Direct | > SS | Low
Man vs. ST | Mixed | NS | SF-36: B, C296 | L | - | NA | Direct | = S-NS | Low
Man vs. ST | Unknown | S | - | - | - | - | - | - | Insufficient
Man vs. ST | Unknown | NS | - | - | - | - | - | - | Insufficient
Man^**^ vs. ST | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. ST | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Man^**^ vs. ST | Chronic | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. ST | Chronic | NS | - | - | - | - | - | - | Insufficient
Man^**^ vs. ST | Mixed | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. ST | Mixed | NS | VAS: C, D, E66 | M | - | NA | Direct | = S-NS | Low
Man^**^ vs. ST | Mixed | NS | RMDQ: C, D, E66 | M | - | NA | Direct | = S-NS | Low
Man^**^ vs. ST | Mixed | NS | % pts using NSAIDs or muscle relaxants: D66 | M | - | NA | Indirect | > SS | Low
Man^**^ vs. ST | Unknown | S | - | - | - | NA | - | - | Insufficient
Man^**^ vs. ST | Unknown | NS | Oswestry: E95 | M | - | NA | Direct | > SS | Low
Man^**^ vs. ST | Unknown | NS | SLR (right): E95 | M | - | NA | Indirect | > SS | Low
Man^**^ vs. ST | Unknown | NS | SLR (left): E95 | M | - | NA | Indirect | = S-NS | Low
Man^**^ vs. ST | Unknown | NS | % pts taking analgesics: E95 | M | - | NA | Indirect | = S-NS | Low
Man^**^ vs. ST | Unknown | NS | % pain-free pts: E95 | M | - | NA | Indirect | = S-NS | Low
Man^**^ vs. ST | Unknown | NS | ROM (flx): E95 | M | - | NA | Indirect | = S-NS | Low
Man vs. Ma | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man vs. Ma | Acute/subacute | NS | VAS: B101 | H | - | NA | Direct | = S-NS | Low
Man vs. Ma | Acute/subacute | NS | ROM (etx, flx): B101 | H | - | NA | Indirect | = S-NS | Low
Man vs. Ma | Acute/subacute | NS | SLR: B101 | H | - | NA | Indirect | = S-NS | Low
Man vs. Ma | Chronic | S | - | - | - | - | - | - | Insufficient
Man vs. Ma | Chronic | NS | N days of pain relief: B, C292 | M | - | NA | Indirect | > SS | Low
Man vs. Ma | Mixed | S | - | - | - | - | - | - | Insufficient
Man vs. Ma | Mixed | NS | ROM (walking, bending, twisting): B295 | H | - | NA | Indirect | .= S-NS | Low
Man vs. Ma | Mixed | NS | ROM (sitting, reaching, dressing): B295 | H | - | NA | Indirect | > SS | Low
Man vs. Ma | Mixed | NS | SLR: B295 | H | - | NA | Indirect | = S-NS | Low
Man vs. Ma | Unknown | S | - | - | - | - | - | - | Insufficient
Man vs. Ma | Unknown | NS | - | - | - | - | - | - | Insufficient
Man vs. TENS | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man vs. TENS | Acute/subacute | NS | VAS: B101 | H | - | NA | Direct | = S-NS | Low
Man vs. TENS | Acute/subacute | NS | ROM (etx, flx): B101 | H | - | NA | Indirect | = S-NS | Low
Man vs. TENS | Acute/subacute | NS | SLR: B101 | H | - | NA | Indirect | = S-NS | Low
Man vs. TENS | Chronic | S | - | - | - | - | - | - | Insufficient
Man vs. TENS | Chronic | NS | - | - | - | - | - | - | Insufficient
Man vs. TENS | Mixed/Unknown | S | - | - | - | - | - | - | Insufficient
Man vs. TENS | Mixed/Unknown | NS | - | - | - | - | - | - | Insufficient
Man^**^ vs. Ex | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. Ex | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Man^**^ vs. Ex | Chronic | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. Ex | Chronic | NS | VAS: B, C, D299 | M | - | NA | Direct | > SS | Low
Man^**^ vs. Ex | Chronic | NS | Oswestry: B, C, D299 | M | - | NA | Direct | > SS | Low
Man^**^ vs. Ex | Chronic | NS | % pts on sick leave: B, D299 | M | - | NA | Indirect | > SS | Low
Man^**^ vs. Ex | Chronic | NS | Patient-Specific Functional Scale: C39 | M | - | NA | Direct | > SS | Low
Man^**^ vs. Ex | Chronic | NS | Global perceived Effect: C39 | M | - | NA | Direct | > SS | Low
Man^**^ vs. Ex | Mixed | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. Ex | Mixed | NS | - | - | - | - | - | - | Insufficient
Man^**^ vs. Ex | Unknown | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. Ex | Unknown | NS | - | - | - | - | - | - | Insufficient

S=specific; NS=nonspecific; SS=statistically significant; S-NS=statistically nonsignificant; Man=manipulation; Acu=acupuncture; Ma=massage; Mob=mobilization; PL=placebo; Tx=treatment. Med=medication(s); Int=intervention; PT=physiotherapy; ST=standard therapy; E-acu=electro-acupuncture; MR=muscle relaxation; TENS= transcutaneous electrical nerve stimulation; Ex=exercise; TrP=trigger point; VAS=visual analog scale; RMDQ=Roland Morris Disability scale; NHP=Nottingham Health Profile; PPT= pressure pain threshold; HFAQ=Hanover functional ability questionnaire; MPQ=McGill pain questionnaire; ext=extension; flx=flexion; rot=rotation; PDI=pain disability index; min=minute(s); hr(s)=hour(s); L=low; M=medium; H=high; pt(s)=patient(s); SF=short-form; NPQ=neck pain questionnaire; GWBS=global well-being scale; SLR=straight leg raising; GPE= Global perceived effect; NSAIDS=nonsteroidal antiinflammatory drugs; FTF=finger-to-floor; SF-PQ=short form pain questionnaire; PRI=pain rating index; PPI=present pain intensity; NA=not applicable

^ψ^Grade (High, moderate, low, and insufficient)

^**^ Manipulation in combination with mobilization

^£^ Number of pooled trials

^#^ Abstract

B = immediate post-treatment

C = short-term post-treatment

D = intermediate-term post-treatment

E = long-term post-treatment

H = high

L = low

M = medium

- No evidence

= Similar beneficial effect

> Favors treatment A over treatment B

< Favors treatment B over treatment A

><, =>, <= Inconsistent beneficial effect

Population with acute/subacute pain. This sub-section included 11 trials.20,55,57,101,123,274,277,284,287,290,291 All trials enrolled subjects with nonspecific LBP. Results from two trials, comparing manipulation to massage,101 or manipulation to mobilization55 are presented in the Acute or Sub-Acute LBP sub-sections of Massage and Mobilization sections.

Subjects with specific pain.

Manipulation versus placebo. No relevant studies were identified.

Manipulation versus no treatment. No relevant studies were identified.

Manipulation versus another type/method of the Same CAM. No relevant studies were identified.

Manipulation versus other treatments. No relevant studies were identified.

Manipulation versus medication. No relevant studies were identified.

Manipulation + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Manipulation versus placebo. In five trials,20,57,277,284,291 manipulation was compared to placebo at immediate or short-term post-treatment followup, indicating significantly greater improvements for manipulation versus placebo groups in reducing immediate or short-term post-treatment pain intensity (VAS). In contrast, there were no between-group differences in disability (Oswestry),57 flexibility/mobility,20,57 or pain medication use.57 For example, in one trial,277 manipulation was significantly superior to placebo in relieving pain in subjects with or without neurological signs at short term followup (four-point VAS; p< 0.01). Intermediate-term post-treatment data of the same trial showed no significant difference in relieving pain between the groups of manipulation and placebo. In another trial,284 subjects randomized to manipulation had significantly better immediate-term post-treatment pain intensity (percentage of pain-free subjects: 92.0 percent versus 25.0 percent, p < 0.01) and mobility (improvement on Schober’s test: 100.0 percent versus 50.0 percent, p < 0.01) compared to those randomized to placebo (i.e., simulated short-wave therapy).

Manipulation versus no treatment. The use of manipulation, compared to ‘no treatment’ was associated with a significantly lower immediate post-treatment pain intensity on five-point VAS (p = 0.03).291

Manipulation versus another type/method of the same CAM. No relevant studies were identified.

Manipulation versus other treatments. In one trial,20, post-treatment differences in pain intensity (VAS), disability (Oswestry), depression score (modified Zung scale), integrated electromyographic activity (EMG(, and maximal voluntary contraction were not significant between the manipulation and the muscle relaxation groups.

In another study,277 at short term post-treatment followup, manipulation was more efficacious in relieving pain four-point VAS) and improving function (using a four-point disability questionnaire) compared to bed rest or physiotherapy (massage, analgesic currents and diathermy) in subjects with acute pain. However, this advantage was not sustained at 6 months followup in both groups of subjects with or without radiating pain. In this trial, a subgroup of subjects with acute pain and a chronic history of pain were randomized to manipulation versus physiotherapy, low back school, or bed rest. Manipulation therapy at short term (3 weeks, 2 months) followup was significantly better in reducing pain intensity than back school or placebo. For the same period, physiotherapy was shown to be more effective in relieving pain and improving function than manipulation. At intermediate (6 months) post-treatment followup, manipulation was better than placebo but did not differ from physiotherapy or back school.(numerical data not reported; only graphs were presented).277

In two trials,101,290 manipulation did not differ from myofascial therapy (alone or combined with manipulation),290 TENS,101 or corset101 in improving pain intensity (VAS),101,290 disability (RMDQ),290 or range of mobility (straight leg raising, pelvic flexion/extension, Schober’s test),101 immediately after the end of treatment.

In one trial,123 manipulation combined with best care had a modest improvement compared to best care alone or combined with exercise in disability and pain.

Manipulation versus medication. In one trial,287 there were no significant post-treatment differences between the manipulation and medication (e.g., antiinflammatory agents) groups with respect to reduction in pain intensity or disability.

In another study,277 at short term post-treatment followup, manipulation was more efficacious in relieving pain (4-point VAS) and improving function (using 4-point disability questionnaire) compared to drug therapy in subjects with acute pain. This advantage was not sustained at 6 months followup. In this trial, a subgroup of subjects with acute pain in a chronic history of pain were also randomized to manipulation versus drug therapy. For 3 weeks and 2 months post-treatment periods, drug therapy was shown to be more effective in relieving pain and improving function than manipulation. At intermediate (6 months) post-treatment followup, manipulation did not differ from drug therapy (numerical data not reported; only graphs were presented).277

Manipulation + other treatments versus the same other treatments. In one trial,274 short-term post-treatment pain intensity (VAS: 0.0 ± 0.0 versus 13.57 ± 9.40, p < 0.0005), ROM (flexion: 45.60 ± 6.95 versus 31.14 ± 7.48, p < 0.0005), and disability (RMDQ: 0.33 ± 0.82 versus 3.64 ± 2.80, p < 0.001) were significantly better in the manipulation + exercise group compared to the exercise alone group.

Population with chronic pain. This sub-section included 12 trials.51,119,140,276,277,279-281,286,289,292,293 All trials studied subjects with nonspecific LBP. See additional results of one trial 51 in the Acupuncture, Chronic LBP section. See result for another trial,279 in the Mobilization, Chronic LBP section.

Subjects with specific pain.

Manipulation versus placebo. No relevant studies were identified.

Manipulation versus no treatment. No relevant studies were identified.

Manipulation versus another type/method of the same CAM. No relevant studies were identified.

Manipulation versus other treatments. No relevant studies were identified.

Manipulation versus medication. No relevant studies were identified.

Manipulation + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Manipulation versus placebo. The effects of manipulation and placebo were compared in three trials.119,277,293 In these trials, manipulation was associated with significantly greater improvements in pain (VAS) compared to placebo.

In the first trial,119 immediately after the treatment, subjects in the manipulation group had a significantly improved disability level (i.e., decreased Oswestry scores) compared to those in placebo group (9.5 ± 6.3 versus 15.5 ± 10.8, p = 0.012). Although the observed difference 2 weeks after the treatment was numerically in favor of manipulation, compared to placebo, this difference did not reach the traditional level of statistical significance (10.6 ± 11.7 versus 14.0 ± 11.7, p = 0.41).119

In the second trial,293 the improvement in post-treatment pain intensity (VAS) was numerically greater in the manipulation versus placebo group immediately (1.3 versus 0.7, p-value for between-group comparison not reported) or short-term post-treatment (2.3 versus 0.6, p-value for between-group comparison not reported).

In the third trial,277 manipulation was significantly better in reducing short- and intermediate-term post-treatment pain intensity (4- point VAS) compared to placebo in patients with chronic LBP with or without radiating pain. This trial failed to report numeric data.

Manipulation versus no treatment. In one trial,281 subjects randomized to manipulation and ‘no treatment’ were compared with respect to flexion-relaxation degree. In this trial, the post-treatment flexion-relaxation degree did not differ between subjects in the manipulation and ‘no treatment’ groups.

Manipulation (type 1) versus manipulation (type 2). In one trial,289 the short-term post-treatment effect on pain (NRS-11) and functional disability (the Modified Von Korff Scales - MVK) was significantly increased for subjects who received a greater number of manipulation treatments whether alone or combined with physical therapy.289

Manipulation versus other treatments. In two trials, manipulation was shown to produce significantly greater immediate post-treatment improvements in pain (VAS, NRS), disability (RMDQ, Oswestry), and ROM (lumbar flexion and extension) compared to massage,292 or ultrasound.286

In one trial,277 at 3 weeks post-treatment, physiotherapy (massage, and physical modalities) was more effective compared to manipulation or back school in patients without radiating pain. In this subgroup, patients originally randomized to manipulation showed significantly more improvement compared to back school (or placebo) at 3 weeks and 2 months but not at 6 months followup. The same trial, but in a subgroup of patients with radiating back pain, showed more improvement in pain and function with manipulation than back school at 3 weeks but not at 2 months or 6 months of followup. Physiotherapy and low back school were more effective than manipulation in both 2 months and 6 months followup. This trial failed to report numeric data.277

In another trial,280 subjective analgesic effect of back school program was significantly better compared to manipulation in patients with sacroiliac joint pain immediately after the treatment.

Manipulation versus medication. In one trial,277 at 3 weeks, short term- and intermediate-term post-treatment, spinal manipulation was not significantly different from drug therapy in reducing pain (4-point VAS; no numeric data were given). In contrast, in two other trials,51,140 subjects in manipulation groups experienced significantly greater immediate post-treatment reductions in pain intensity (VAS score: 38.0 percent -50.0 percent) and disability (Oswestry score: 30.7 percent -50.0 percent) compared with subjects in the medication groups.

Manipulation + other treatments versus the same other treatments. In one trial,276 at short-and intermediate-term after the treatment, manipulation combined with exercise did not significantly differ from exercise alone in improving pain (VAS).

Manipulation versus manipulation + other treatments. In one trial,289 the short-term post-treatment effect on pain (NRS-11) and functional disability (the Modified Von Korff Scales - MVK) did not differ between manipulation alone or combined with physical therapy.289

Population with mixed duration of pain. This sub-section included 10 trials.31,104,230,275,278,283,288,294-296 Of the nine trials, two studied subjects with specific LBP (e.g., disc protrusion, sciatica).230,275

Subjects with specific pain.

Manipulation versus placebo. No relevant studies were identified.

Manipulation versus no treatment. No relevant studies were identified.

Manipulation versus another type/method of the same CAM. No relevant studies were identified.

Manipulation versus other treatments. The immediate and short-term post-treatment effects of manipulation and infra-red therapy were compared in subjects with sciatica.230 Similar recovery rates (percentage of pain-free subjects) were found between the two groups amongst subjects with normal straight leg raise (58.0 percent versus 68.0 percent, p > 0.05). In contrast, amongst subjects with restricted straight leg raise, the between-group difference in recovery rate was significant, favoring subjects in the manipulation group over infra-red therapy group (77.2 percent versus 56.6 percent, p < 0.05).

In one trial, 11,128 subjects with disc protrusion who received a combination of manipulation and physiotherapy (traction, microwave and other modalities) had significantly greater healing (73.4 percent versus 47.3 percent, p < 0.01) and effective rates (98.6 percent versus 96.4 percent, p < 0.01) compared to subjects who received physiotherapy alone.275

Manipulation versus medication. No relevant studies were identified.

Manipulation + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Manipulation versus placebo. In one trial,104 the immediate post-treatment back pain improvement (percent change on VAS) was numerically greater in the manipulation group compared to placebo group (statistical test results were not provided). The beneficial effect of manipulation relative to placebo was more evident in subjects under 40 years (compared to subjects 40 years or older) or subjects with sub-acute LBP (versus subjects with acute LBP).104

Manipulation versus no treatment. In one trial,288 subjects randomized to receive manipulation, experienced significant reduction (from baseline) in immediate/short-term post-treatment pain intensity (VAS: 12.20 versus 10.40, p < 0.05). In contrast, subjects randomized to no treatment group, did not experience significant reduction in pain intensity (p = 0.10).

Manipulation (type 1) versus manipulation (type 2). In one trial,294 subjects with sub-acute and chronic LBP who received upper cervical adjustment as well as upper cervical + full spine adjustment experienced significant improvement in pain intensity (VAS score) compared to baseline. The group of subjects who received full spine adjustment only, did not improve in pain intensity (VAS) but did improve in disability (Oswestry score). Numerical data for these groups were not reported.

Manipulation versus other treatments. In one trial,278 short-term post-treatment effects of manipulation and ‘educational booklet’ were compared and no significant differences in pain (11-point pain scale measuring symptom bothersomeness: 2.0 ± 2.2 versus 3.2 ± 3.2, p = 0.06) or disability (RMDQ: 3.1 ± 4.1 versus 4.1 ± 4.9, p = 0.28) were found between the two groups. In the same trial, no significant differences were found in short-term post-treatment effects on pain (percentage of pain-free subjects, 11-point pain scale) or disability (RMDQ) between manipulation and physiotherapy (McKenzie technique based on diagnoses of derangement, dysfunction or postural syndromes). In another trial,296 high or low velocity spinal manipulation (SM) was compared to minimal conservative medical care (aiming to improve pain with optimization of activities of daily living with patient specific choice of medication) in older adults. Spinal manipulation was significantly more effective compared to medical care alone in improving immediate, short-, or intermediate-term post-treatment disability (adjusted RMDQ score: 0-24) and perception of global improvement (score: 1-10), but not pain (VAS score: 0-100) or physical function (SF-36 score: 0-100). The adjusted RMDQ mean change from baseline values in the high and low velocity manipulation and medical care groups were 2.7 (95 percent CI: 2.0, 3.3), 2.9 (95 percent CI: 2.2, 3.6), and 1.6 (95 percent CI: 0.5, 2.8), respectively.

Manipulation versus other CAM treatments. In one trial,295 subjects in the manipulation groups did not significantly differ from subjects in the massage group, with respect to straight leg raising.295 In this trial, the data immediately after the end of treatment indicated significantly better spinal flexibility (e.g., walking, bending, twisting, sitting down in a chair, reaching, dressing) in the manipulation group compared to the massage group.295

In one trial,296 high velocity spinal manipulation was similar to low velocity manipulation in reducing immediate, short term- and intermediate-term post treatment pain intensity (VAS score: 0-100) or disability (Oswestry score: 0-24) in adults ≥ 55 years or older. Both treatment methods were effective in the reduction of LBP symptoms.

Manipulation versus medication. The results of one underpowered trial283 indicated statistically nonsignificantly greater proportion of pain-free subjects in the manipulation versus medication group (50.0 percent versus 11.0 percent, p = 0.15), and therefore were rendered as inconclusive. In another trial,104 the immediate post-treatment back pain improvement (percent change on VAS) was numerically greater in the manipulation group compared to the medication group (statistical test results were not provided). The beneficial effect of manipulation relative to medication was more evident in subjects under 40 years (compared to subjects 40 years or older) or subjects with sub-acute/chronic LBP (versus subjects with acute LBP).104

Manipulation + other treatments versus the same other treatments. In one trial,31 131 subjects were randomized to either a combination of manipulation and exercise or exercise alone for 4 weeks. The subjects then were grouped into positive and negative subgroups according to whether or not they met a pre-specified set of 5 criteria (duration of current episode < 16 days, no symptoms distal to the knee, FABQ work subscale score < 19, ≥ 1 hypomobile lumbar spine segment, ≥ 1 hip with > 35 degrees of internal rotation range motion). Immediately after the end of treatment, the rate of success (> 50.0 percent improvement on Oswestry disability scale) in the manipulation group was significantly greater compared to the exercise alone group (62.9 percent versus 36.1 percent, p = 0.002). At intermediate-term post-treatment followup, the mean Oswestry disability score was significantly lower in subjects receiving manipulation plus exercise compared to those receiving exercise alone (mean between-group difference: 10.1, 95 percent CI: 4.3, 15.9, p = 0.001). Moreover, medication use and healthcare utilization was significantly lower in the manipulation group compared to the exercise group. The subgroup analysis indicated that the greatest treatment effect of manipulation relative to exercise was observed for subjects classified as positive on the prediction rule (i.e., meeting at least 4 of the 5 criteria). In the same trial,31,35 the subject’s age, gender, symptom duration, or the therapist’s years of experience did not have a significant effect on the mean change on Oswestry score. This study also reported an increased risk of worsening disability for patients who did not receive spinal manipulation (11 percent versus 3 percent in exercise group and spinal manipulation + exercise group respectively; RR = 8.0, 95 percent CI: 1.1, 63.5) measured by Oswestry disability scores obtained at 6 months of followup. In addition, failure rates were higher in subgroup of patients with hypomobility (74.4 percent versus 26 percent in exercise versus manipulation + exercise groups respectively). However, patients with hypermobility were more likely to benefit from stabilizing exercise than spinal manipulation + exercise (failure rates of 22.0 percent versus 83.3 percent in exercise and spinal manipulation + exercise groups respectively).

Population with unknown duration of pain. This sub-section included two trials,282,285 one of which was restricted to subjects with specific LBP (degenerative spondylolisthesis)282 and the other to subjects with nonspecific LBP (i.e., sacroiliac joint syndrome).285

Subjects with specific pain.

Manipulation versus placebo. No relevant studies were identified.

Manipulation versus no treatment. No relevant studies were identified.

Manipulation (type 1) versus manipulation (type 2). In one trial,282 fine adjusting manipulation was associated with a significantly greater therapeutic effect (percentage of pain free subjects) compared to that for the reduction manipulation in subjects with degenerative spondylolisthesis (60.0 percent versus 36.7 percent, p < 0.05).

Manipulation versus other treatments. No relevant studies were identified.

Manipulation versus medication. No relevant studies were identified.

Manipulation + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Manipulation versus placebo. No relevant studies were identified.

Manipulation versus no treatment. No relevant studies were identified.

Manipulation (type 1) versus manipulation (type 2). In one trial,285 although routine manipulation and manually assisted manipulation using Activator Adjusting Instrument (AAI) produced statistically significant reductions in pain (NRS) and disability (Oswestry) for subjects with sacroiliac joint syndrome, the between-group differences for these outcomes were not significant.

Manipulation versus other treatments. No relevant studies were identified.

Manipulation versus medication. No relevant studies were identified.

Manipulation + other treatments versus the same other treatments. No relevant studies were identified.

#### 4 Manipulation + Mobilization for treatment of Low Back Pain

There were 10 trials identified for this section. Results of six studies were reported in multiple publications (Table 3).

Population/trial characteristics. These trials were conducted in Australia (two),39,56 Ireland (one),300 the Netherlands (one),84 Norway (one),299 UK (four),95,108,301,302 and US (one).66

The proportion of men and women were similar in eight trials.56,66,84,95,108,299,300,302 In one trial,39 the majority of subjects were females.

The number of study participants in these trials ranged from 49^299^ to 741^95^ with a total of 2,838 subjects in all trials combined. Table 12 presents the control interventions in the included studies.

Table 12 Spinal manipulation + mobilization for treatment of low back pain- Control interventions

Type of control group | Cause of Pain | N studies | Detail of Control intervention
1 – Inactive treatments
Placebo/sham | Non Specific | 1 | sham manipulation + mobilization and placebo Diclofenac (double placebo),56low intensity microwave108
Placebo/sham | Specific | 0 | NA
2 – Active treatments
Exercise/physical activity | Non Specific | 2 | motor control exercise (retraining specific trunk muscles using ultrasound feedback),39 general and individualized exercise programs (strengthening, stretching, mobilizing, coordination, and stabilizing exercise for the abdominal, back, pelvic, and lower limb muscles according to clinical findings)299
Exercise/physical activity | Specific | 0 | NA
Usual care | Non Specific | 2 | Medical care alone,66 in combination with physical modalities66 Conventional outpatient care95
Usual care | Specific | 0 | NA
Education | Non Specific | | Educational booklet302
Education | Specific | 0 | NA
Physiotherapy | Nonspecific | 1 | Manual therapy and physical modalities (exercise, massage, heat, electrotherapy, ultrasound, short-wave diathermy)84
Physiotherapy | Specific | 0 | NA

NA= not applicable;

The duration of treatments varied from four to 12 weeks and the frequency of treatments were at least twice a week.

Risk of bias. The risk-of-bias graph for the trials included in this sub-section is presented in Figure 28. All trials were randomized. The adequate method of randomization and treatment allocation concealment was reported for 67.0 percent and 44.0 percent of the trials, respectively. Up to 89.0 percent of the trials reported that distribution of the subjects’ baseline characteristics across the treatment arms was similar. The subjects were reported to be blinded in only 22.0 percent of the trials. About 78.0 percent of the trials reported acceptable drop-out rate. Results based on intention-to-treat analysis were explicitly reported for 44.0 percent of the trials.

Figure 28 Risk of bias scores (%)

Figure 28 depicts the Risk of bias scores percents as a bar graph. On the left hand side are listed, vertically, Q1 through Q13. A horizontal solid black line represents Yes, a gray line, No, and a dotted line, Unclear. At the bottom, left to right, are the percentages 0%, 20%, 40%, 60% 80%, and 100%. Q1 is Yes 0 to about 70%, Unclear, 70% to 100%. Q2 is Yes 0 to about 45%, No about 45% to about 55%, and Unclear, about 55% to 100%. Q3 is Yes 0% to about 90%, No about 90% to 100%. Q4 is Yes 0% to 20%, No 20% to about 90%, and Unclear about 90% to 100%. Q5 is No 0% to about 80%, and Unclear about 80% to 100%. Q6 is Yes 0% to about 70%, Unclear about 70% to 100%. Q7 is Yes 0% to about 50%, Unclear about 50% to 100%. Q8 is Yes 0% to about 25%, No about 25% to about 45%, and Unclear 45% to 100%. Q9 is Yes 0% to just under 80%, No just under 80% to just under 90%, and Unclear just under 90% to 100%. Q10 is Yes 0% to 90%, Unclear 90% to 100%. Q11 is Yes 0% to about 45%, No about 45% to about 55%, and Unclear about 55% to 100%. Q12 is Yes 0% to about 55%, No about 55% to 100%. Q13 is Yes 0% to about 10%, 10% to about 25%, and Unclear about 25% to 100%.

Efficacy results. A summary of the key results is presented in Table 11. For more details please see evidence tables. (Appendix C, table 1.21 – table 1.27)

Population with acute/subacute pain. There were two trials56,300 included in this sub-section. Both trials were restricted to subjects with LBP due to nonspecific causes.

Subjects with specific pain.

Manipulation + mobilization versus placebo. No relevant studies were identified.

Manipulation + mobilization versus no treatment. No relevant studies were identified.

Manipulation + mobilization versus another type/method of the same CAM. No relevant studies were identified.

Manipulation + mobilization versus other treatments. No relevant studies were identified.

Manipulation + mobilization versus medication. No relevant studies were identified.

Manipulation + mobilization + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Manipulation + mobilization versus placebo. In one trial,56 manipulation + mobilization was compared to double placebo (sham manipulation and placebo medication) and the results indicated nonsignificant differences in time to achieve recovery, post-treatment pain intensity (VAS), disability (RMDQ), and global perceived effects between the two groups.

Manipulation + mobilization versus no treatment. No relevant studies were identified.

Manipulation + mobilization versus another type/method of the same CAM. No relevant studies were identified.

Manipulation + mobilization versus other treatments. In one trial,300 post-treatment pain intensity (VAS, MPQ), quality of life (SF-36), disability (RMDQ), and range of mobility (e.g., flexion, functional activity) did not differ between the combination of manipulation and mobilization and inferential therapy at short- intermediate-, or long-term followup periods. In another trial,301 patients in manipulation + mobilization group had significantly lower number of treatments to reach a symptom free status than those in microwave diathermy group. There was also a statistically significant difference between the intervention and control group in lumbar extension favoring manipulation + mobilization immediately post 3 weeks of treatment (p < 0.05) but not for any other objective measures. In both trials, manipulation + mobilization treatments were delivered by experienced physiotherapists.

Manipulation + mobilization + other treatments versus the same other treatments. No relevant studies were identified.

Population with chronic pain. There were two trials39,299 included in this sub-section. Both trials were restricted to subjects with LBP due to nonspecific causes.

Subjects with specific pain.

Manipulation + mobilization versus placebo. No relevant studies were identified.

Manipulation + mobilization versus no treatment. No relevant studies were identified.

Manipulation + mobilization versus another type/method of the same CAM. No relevant studies were identified.

Manipulation + mobilization versus other treatments. No relevant studies were identified.

Manipulation + mobilization versus medication. No relevant studies were identified.

Manipulation + mobilization + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Manipulation + mobilization versus placebo. No relevant studies were identified.

Manipulation + mobilization versus no treatment. No relevant studies were identified.

Manipulation + mobilization versus another type/method of the same CAM. No relevant studies were identified.

Manipulation + mobilization versus other treatments. In one trail,299 the manual therapy group showed significantly greater improvements than the exercise therapy group on pain intensity, functional disability, general health and return to work throughout the 2 months intervention in group of sick-listed patients. Immediately after the 2 month treatment period, 67 percent in the manual therapy and 27 percent in the exercise therapy group had returned to work (p < 0.01), a relative difference that was maintained throughout followup.

In another trial,39 motor control exercise (retraining specific trunk muscles using ultrasound feedback) and manipulation + mobilization produced slightly better short-term function (mean difference on Patient-Specific Functional scale: 2.30, 95 percent CI: 0.4, 4.2) and perceptions of effect (mean Global Perceived Effect difference: 1.20, 95 percent CI: 0.4, 2.0) than general exercise group, but not better intermediate or long-term effects,. There was no significant difference between the manipulation and motor control exercise in function (mean difference: 0.4, 95 percent CI: -1.5, 2.4) or global perceived effect (mean difference: 0.5, 95 percent CI: -0.2, 1.1).

Manipulation + mobilization versus medication. No relevant studies were identified.

Manipulation + mobilization + other treatments versus the same other treatments. No relevant studies were identified.

Population with mixed duration of pain. This sub-section included three trials restricted to subjects with nonspecific LBP.66,84,302

Subjects with specific pain.

Manipulation + mobilization versus placebo. No relevant studies were identified.

Manipulation + mobilization versus no treatment. No relevant studies were identified.

Manipulation + mobilization versus another type/method of the same CAM. No relevant studies were identified.

Manipulation + mobilization versus other treatments. No relevant studies were identified.

Manipulation + mobilization versus medication. No relevant studies were identified.

Manipulation + mobilization + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Manipulation + mobilization versus placebo. No relevant studies were identified.

Manipulation + mobilization versus no treatment. No relevant studies were identified.

Manipulation + mobilization versus another type/method of the same CAM. No relevant studies were identified.

Manipulation + mobilization versus other treatments. In one trial,66 the combination of manipulation and mobilization (with or without physical modalities) was not significantly different from medical care alone or medical care combined with physical modalities (in reducing pain (VAS) and disability (RMDQ) at short, intermediate, and long-term time points post-treatment. Throughout the followup, the use of prescription drugs (e.g., NSAIDs, muscle relaxants, analgesics) was significantly greater in the medical care group versus manipulation group (at 6 months: 32.0 percent versus 24.0 percent). The mean number of doctor visits during 6 months of followup was greater among subjects in the manipulation versus medical care group (5.4 versus 2.9). Chiropractors administered the manual treatment in this trial.

Similarly, another trial,302 did not find any significant differences in disability (i.e., Disability Index) between subjects receiving osteopathic manipulation versus ‘educational booklet.’

In one trial,84 the combination of manipulation and mobilization produced significantly greater improvements in intermediate- and long-term post-treatment pain intensity(10-point scale: minimal severity = 1, maximal severity = 10) and physical functioning (10-point scale) compared to physiotherapy (exercise, massage, heat, electrotherapy, ultrasound, short-wave diathermy). The global perceived effect (six-point scale) did not differ between subjects who received manipulation plus mobilization and physiotherapy (intermediate-term post-treatment: 3.5 ± 1.9 versus 3.5 ± 1.8, p > 0.05).84 The subgroup analysis of the same trial85 revealed that the beneficial effect of manipulation compared to physiotherapy was maximized in subjects with chronic pain (longer than one year) and in subjects younger than 40 years old. The manual therapy was delivered by physiotherapist who had an additional three years of training in manipulation.

Manipulation + mobilization versus medication. No relevant studies were identified.

Manipulation + mobilization + other treatments versus the same other treatments. No relevant studies were identified.

Population with unknown duration of pain. This sub-section included two trials with subjects having nonspecific LBP.95,108

Subjects with specific pain.

Manipulation + mobilization versus placebo. No relevant studies were identified.

Manipulation + mobilization versus no treatment. No relevant studies were identified.

Manipulation + mobilization versus another type/method of the same CAM. No relevant studies were identified.

Manipulation + mobilization versus other treatments. No relevant studies were identified.

Manipulation + mobilization versus medication. No relevant studies were identified.

Manipulation + mobilization + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Manipulation + mobilization versus placebo. In one trial,108 the combination of manipulation and mobilization did not significantly improve immediate-, short-, or intermediate-term post-treatment lumbar mobility (flexion, extension, straight leg raising) compared to placebo (microwave at a very low setting). For example, mean values for extension in the combination and placebo groups immediately after the end of treatment were 42.96 ± 9.09 and 44.43 ± 11.38, respectively (p > 0.1). The corresponding values for flexion were 2.40 ± 10.30 and 22.75 ± 9.62, respectively (p > 0.1). Treatments were delivered by trained physiotherapists.

Manipulation + mobilization versus no treatment. No relevant studies were identified.

Manipulation + mobilization versus another type/method of the same CAM. No relevant studies were identified.

Manipulation + mobilization versus other treatments. In one trial,95 subjects receiving manipulation plus mobilization (delivered by trained chiropractor) had significantly improved long-term post-treatment pain (percentage of pain-free subjects), disability (Oswestry) and straight leg raising compared to those receiving conventional care. The use of analgesics did not differ between the two groups. The combination group had a significantly fewer subjects who were absent from work (percentage of subjects taking time off work) compared to the conventional care group. The subjects with severe disability at entry (Oswestry > 40.0 percent) responded more favorably than subjects with less severe disability at entry (Oswestry ≤ 40.0 percent).

Manipulation + mobilization versus medication. No relevant studies were identified.

Manipulation + mobilization + other treatments versus the same other treatments. No relevant studies were identified.

#### 5 Flexion Distraction for Treatment of Low Back Pain

There were four trials identified and included in this sub-section. All four trials recruited participants with nonspecific pain.

Population/trial characteristics. All four trails were conducted in US. One of these trials was of particularly small sample size (only 13 subjects).303

Two of these trials reported information on ethnicity,304,305 and two trials reported the proportion of men and women in the trial.303,305

In total, there were 576 subjects randomize to flexion distraction technique therapy or control groups. The number of study participants ranged from 13 in one trial,303 to 235 in the largest trial.305 Control interventions were:

- Placebo (two studies)303,304
- Other treatments (two studies) including physical modalities,297, and exercise305

The duration of treatments varied from 1 to 4 weeks. The frequency of treatments varied from twice a week to four times a week.

Risk of bias. The risk-of-bias graph for the trials included in this sub-section is presented in Figure 29. All trials were randomized. The adequate method of randomization and treatment allocation concealment was reported for 25.0 percent and 50.0 percent of the trials, respectively. Up to 50.0 percent of the trials reported that distribution of the subjects’ baseline characteristics across the treatment arms was similar. The subjects were reported to be blinded in 50.0 percent of the trials. All of the trials reported acceptable drop-out rate. Results based on intention-to-treat analysis were explicitly reported for 25.0 percent of the trials.

Figure 29 Risk of bias scores (%)

Figure 29 depicts the Risk of bias scores percents as a bar graph. On the left hand side are listed, vertically, Q1 through Q13. A horizontal solid black line represents Yes, a gray line, No, and a dotted line, Unclear. At the bottom, left to right, are the percentages 0%, 20%, 40%, 60% 80%, and 100%. Q1 is Yes 0 to about 25%, Unclear, about 25% to 100%. Q2 is Yes 0 to about 50%, Unclear, about 50% to 100%. Q3 is Yes 0% to about 50%, No about 50% to about 75%, and Unclear about 75% to 100%. Q4 is Yes 0% to 50%, No 50% to about 70%, and Unclear about 70% to 100%. Q5 is No 0% to about 50%, and Unclear about 50% to 100%. Q6 is Unclear 0 to 100%. Q7 is Unclear 0% to 100%. Q8 is Unclear 0 to 100%. Q9 is Yes 0 to 100%. Q10 is Yes 0 to 100%. Q11 is Yes 0% to about 25%, No about 25% to about 95%, and Unclear about 95% to 100%. Q12 is Yes 0% to about 75%, No about 75% to 100%. Q13 is Unclear) to 100%.

Population with acute/subacute pain. No relevant studies were identified or included.

Population with chronic pain. Only one trial was included in this section.305

Subjects with specific pain.

Flexion distraction versus placebo. No relevant studies were identified.

Flexion distraction versus no treatment. No relevant studies were identified.

Flexion distraction versus another type/method of the same CAM. No relevant studies were identified.

Flexion distraction versus other treatments. No relevant studies were identified.

Flexion distraction versus medication. No relevant studies were identified.

Flexion distraction + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Flexion distraction versus placebo. No relevant studies were identified.

Flexion distraction versus no treatment. No relevant studies were identified.

Flexion distraction versus another type/method of the same CAM. No relevant studies were identified.

Flexion distraction versus other treatments. In one trial,305 the effects of flexion-distraction therapy and physical therapy (exercise program) on short-term post-treatment pain intensity (VAS) and disability (RMDQ) did not significantly differ. After 1 year of care, subjects who received flexion-distraction therapy had a significantly lower mean pain score (VAS) than subjects who received physical therapy (20.6 ± 1.9 versus 21.6 ± 2.0, p = 0.02).

Flexion distraction versus medication. No relevant studies were identified.

Flexion distraction + other treatments versus the same other treatments. No relevant studies were identified.

Population with mixed duration of pain. Two trials were included in this sub-section.303,304 Both trials studied subjects with nonspecific pain

Subjects with specific pain.

Flexion distraction versus placebo. No relevant studies were identified.

Flexion distraction versus no treatment. No relevant studies were identified.

Flexion distraction versus another type/method of the same CAM. No relevant studies were identified.

Flexion distraction versus other treatments. No relevant studies were identified.

Flexion distraction versus medication. No relevant studies were identified.

Flexion distraction + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Flexion distraction versus placebo. In two trials,303,304 comparing the flexion-distraction technique to placebo (hand-held instrument producing effect similar to manual adjustments), no significant differences in disability (RMDQ, Pain Disability Index - PDI) were found between the two groups. The treatment effect was not modified by age, gender, duration of symptoms, or prior treatment with chiropractic therapy.304

Flexion distraction versus no treatment. No relevant studies were identified.

Flexion distraction versus another type/method of the same CAM. No relevant studies were identified.

Flexion distraction versus other treatments. No relevant studies were identified.

Flexion distraction versus medication. No relevant studies were identified.

Flexion distraction + other treatments versus the same other treatments. No relevant studies were identified.

Population with unknown duration of pain. Only one trial was included in this section.297This trial was restricted to subjects with nonspecific pain.

Subjects with specific pain.

Flexion distraction versus placebo. No relevant studies were identified.

Flexion distraction versus no treatment. No relevant studies were identified.

Flexion distraction versus another type/method of the same CAM. No relevant studies were identified.

Flexion distraction versus other treatments. No relevant studies were identified.

Flexion distraction versus medication. No relevant studies were identified.

Flexion distraction + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Flexion distraction versus placebo. No relevant studies were identified.

Flexion distraction versus no treatment. No relevant studies were identified.

Flexion Distraction versus another type/method of the same CAM. No relevant studies were identified.

Flexion distraction versus other treatments. No relevant studies were identified.

Flexion distraction versus medication. No relevant studies were identified.

Flexion distraction + other treatments versus the same other treatments. In one trial,297flexion-distraction combined with hot pack was significantly superior to hot pack alone in reducing pain intensity (VAS) and increasing lumbar ROM in subjects with LBP due to osteoarthritis.

#### 6 Manipulation for Treatment of Neck Pain

This section included 28 trials. Two trials were reported in six publications (Table 3).

The results from seven studies that compared techniques of manipulation and mobilization are presented in this section.65,306-310 Results from two trials51,140 comparing the effectiveness of manipulation and acupuncture are reported in the Acupuncture for Treatment of Neck Pain section.

Population/trial characteristics. The trials were conducted in Australia (three),51,140,311Canada (five),309,312-315 China (one),316 Denmark (one),317 Germany (one),308 South Africa (three),307,318,319 Nigeria (one),320 Spain (three),310,321,322 and United States (eight).65,306,323-328 The information on the country was not reported for two studies.329,330

There was a greater proportion of women (≥ 60 percent) versus men in eight studies,65,310,313,314,323,324,326,328 and greater proportion of men (≥ 60 percent) versus women in two studies.312,320 The proportions of men and women were similar in six studies.51,306,308,317,321,322 The gender distribution was not reported for six studies.309,311,315,325,329,330

Patients in the included trials were adults aged 18 or older. The information regarding ethnicity was reported for only five trials.65,320,323,327,328

In total 1,820 patients were included in these trials. The experimental intervention included spinal manipulation alone or in combination with other treatment (two studies).321,322 In one study,328 two different dosing regiments of spinal manipulation (two randomized arms) were used combined with other treatments.

Control interventions for 29 trials with spinal manipulation or spinal manipulation + other treatments are displayed in Table 13.

Table 13 Spinal manipulation for treatment of neck pain- Control interventions

Type of control group | Cause of Pain | N studies | Detail of Control intervention
1- Inactive treatments
Placebo/sham | Non Specific | 7 | Rotational mobilization,312light hand placement without tension or pressure,308,326light hand placement with slight rotation but no tension or thrust,310sham ultrasound ,330sham manipulation delivered with a deactivated Pettibon,311no description provided,325
| Specific | 0 | NA
No-treatment/ waiting list | Non Specific | 1 | Positioning as spinal manipulation group without any intervention,324
No-treatment/ waiting list | Specific | 0 | NA
2 – Active treatments
Physiotherapy | Nonspecific | 0 | NA
Physiotherapy | Specific (whiplash) | 1 | Active exercises, electrotherapy, ultrasound in soft tissues of the neck region, manual therapy, muscle stretching and multimodal therapy321
Physical modalities | Nonspecific | 1 | TENS,316
Physical modalities | Specific | 0 | NA
Manual therapy | Nonspecific | 5 | Mobilization,65,306,308,309massage,317
Manual therapy | Specific | 0 | NA
Medication | Nonspecific | 4 | Diazepam,329Amitriptyline,331Paracetamol/Acetaminophen,51Tenoxican and Ranitidine,140
Medication | Specific | 0 | NA
Other methods of spinal manipulation | Nonspecific | 6 | Manipulation on contra-lateral side,307,314manipulation to dysfunctional sections of cervical spine only,313cervical and upper thoracic manipulation,318manipulation according to sham endplay findings generated by a computer algorithm,327mechanically assisted manipulation315
Other methods of spinal manipulation | Specific | 1 | Top vs. top and bottom segment adjustments,319
Active treatment (also in manipulation group) | Nonspecific | 2 | Physical modalities (electro-thermal therapy),322sham ultrasound,330
Active treatment (also in manipulation group) | Specific | 0 | NA
Spinal manipulation in combination with another treatment (vs. manipulation alone) | Nonspecific | 1 | Cervical post isometric relaxation,323
| Specific | 0 | NA

NA= not applicable; TENS = transcutaneous electrical nerve stimulation

The majority of studies reported a single treatment session for the length of the trial.65,306,309,310,312-315,324-327,329 One study reported four treatment visits for duration of 2 weeks.323 The remaining studies implemented one or two treatments for a duration of 3 to 11 weeks,319,322 twice a week for total duration of 4 to 10 weeks,51,140,307,318,330,332 and three to five times a week for a total duration of 3 to 12 weeks.320,321

Risk of bias. The risk-of-bias graph for the trials included in this sub-section is presented in Figure 30. All trials were randomized. The adequate method of randomization and treatment allocation concealment was reported for 52.0 percent and 34.0 percent of the trials, respectively.

Figure 30 Risk of bias scores (%)

Figure 30 depicts the Risk of bias scores percents as a bar graph. On the left hand side are listed, vertically, Q1 through Q13. A horizontal solid black line represents Yes, a gray line, No, and a dotted line, Unclear. At the bottom, left to right, are the percentages 0%, 20%, 40%, 60% 80%, and 100%. Q1 is Yes 0 to about 50%. No about 50% to 60% Unclear about 60% to 100%. Q2 is Yes 0 to about 35%, No about 35% to 50%, Unclear, about 50% to 100%. Q3 is Yes 0% to about 65%, No about 65% to about 80%, and Unclear about 80% to 100%. Q4 is Yes 0% to 10%, No 10% to about 70%, and Unclear about 70% to 100%. Q5 is Yes to about 7%, No 7% to about 90%, and Unclear about 90% to 100%. Q6 is Yes 0% to about 35%, No 35% to about 45%, Unclear about 45% to 100%. Q7 is Yes 0% to about 30%, No about 30% to just under 40%, Unclear just under 40% to 100%. Q8 is Yes 0% to about 45%, No about 45% to about 55%, and Unclear about 55% to 100%. Q9 is Yes 0 to 65%, No 65% to about 75%, Unclear about 75% to 100%. Q10 is Yes 0 to about 85%, Unclear about 85% to 100%. Q11 is Yes 0% to 40%, No 40% to 50%, and Unclear 50% to 100%. Q12 is Yes 0% to 70%, No about 70% to about 90%, and Unclear about 90% to 100%. Q13 is Yes 0 to 10%, No 10% to about 25%, and Unclear about 25% to 100%.

About 62.0 percent of the trials reported that distribution of the subjects’ baseline characteristics across the treatment arms was similar. In 72.0 percent of the trials, study participants were not blinded to the treatment. About 66.0 percent of the trials reported acceptable drop-out rate. Results based on intention-to-treat analysis were explicitly reported for 41.0 percent of the trials. The data for selected items of the risk of bias tool across the CAM interventions (acupuncture; spinal manipulation; spinal mobilization; combination of manipulation and mobilization; and massage therapy) is displayed in table 7.2 of Appendix G.

Efficacy results. A summary of the key results is presented in Table 14. For further detail of the trials please see the evidence tables. (Appendix C, table 2.9 – table 2.16)

Table 14 Key results – Manipulation therapy for treatment of neck pain & cervicogenic headaches

CAM therapy | Duration of pain | Cause of pain | Outcome | Risk-of-bias | Precision of the pooled estimate | Consistency | Directness | Finding | GRADE^ψ^
Man vs. No Tx | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man vs. No Tx | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Man vs. No Tx | Chronic | S | - | - | - | - | - | - | Insufficient
Man vs. No Tx | Chronic | NS | - | - | - | - | - | - | Insufficient
Man vs. No Tx | Mixed | S | - | - | - | - | - | - | Insufficient
Man vs. No Tx | Mixed | NS | - | - | - | - | - | - | Insufficient
Man vs. No Tx | Unknown | S | - | - | - | - | - | - | Insufficient
Man vs. No Tx | Unknown | NS | VAS: B324 | M | - | NA | Direct | = S-NS | Low
Man vs. No Tx | Unknown | NS | ROM: B324 | M | - | NA | Indirect | = S-NS | Low
Man vs. PL | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man vs. PL | Acute/subacute | NS | VAS: B308,314 | H | - | Yes | Direct | > SS | Low
Man vs. PL | Chronic | S | - | - | - | - | - | - | Insufficient
Man vs. PL | Chronic | NS | VAS: B, C326,330 | M | - | Yes | Direct | > SS | Moderate
Man vs. PL | Chronic | NS | PPT: B, C326,330 | M | - | Yes | Direct | > SS | Moderate
Man vs. PL | Chronic | NS | NDI: B, C326 | M | - | NA | Direct | > SS | Low
Man vs. PL | Mixed | S | - | - | - | - | - | - | Insufficient
Man vs. PL | Mixed | NS | PPT: B312 | H | - | NA | Direct | > SS | Low
Man vs. PL | Mixed | NS | VAS: B310 | M | - | NA | Direct | > SS | Low
Man vs. PL | Mixed | NS | ROM: B310 | M | - | NA | Indirect | > SS | Low
Man vs. PL | Unknown | S | - | - | - | - | - | - | Insufficient
Man vs. PL | Unknown | NS | VAS: B325 | H | - | NA | Direct | > SS | Low
Man^**^ vs. PL | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. PL | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Man^**^ vs. PL | Chronic | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. PL | Chronic | NS | - | - | - | - | - | - | Insufficient
Man^**^ vs. PL | Mixed | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. PL | Mixed | NS | ROM: B (ext, flx)84 | M | - | NA | Indirect | = S-NS | Low
Man^**^ vs. PL | Mixed | NS | Physical functioning (10-point scale): B84 | M | - | NA | Direct | > S-NS | Low
Man^**^ vs. PL | Unknown | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. PL | Unknown | NS | - | - | - | - | - | - | Insufficient
Man^**^ vs. PT | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. PT | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Man^**^ vs. PT | Chronic | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. PT | Chronic | NS | VAS: B85 | M | - | NA | Direct | > SS | Low
Man^**^ vs. PT | Mixed | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. PT | Mixed | NS | ROM: B (ext, flx)84 | M | - | NA | Indirect | = S-NS | Low
Man^**^ vs. PT | Mixed | NS | Physical functioning (10-point scale): B84 | M | - | NA | Direct | > SS | Low
Man^**^ vs. PT | Unknown | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. PT | Unknown | NS | - | - | - | - | - | - | Insufficient
Man^**^ vs. ST | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. ST | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Man^**^ vs. ST | Chronic | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. ST | Mixed | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. ST | Mixed | NS | ROM: B (ext, flx)84 | M | - | NA | Indirect | = S-NS | Low
Man^**^ vs. ST | Mixed | NS | Physical functioning (10-point scale): B84 | M | - | NA | Direct | > SS | Low
Man^**^ vs. ST | Unknown | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. ST | Unknown | NS | - | - | - | - | - | - | Insufficient
Man^**^ vs. Ex | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. Ex | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Man^**^ vs. Ex | Chronic | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. Ex | Chronic | NS | Headache frequency (mean number per week): B, C83 | M | - | NA | Direct | = S-NS | Low
Man^**^ vs. Ex | Chronic | NS | VAS: B, C83 | M | - | NA | Direct | = S-NS | Low
Man^**^ vs. Ex | Mixed | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. Ex | Mixed | NS | - | - | - | - | - | - | Insufficient
Man^**^ vs. Ex | Unknown | S | - | - | - | - | - | - | Insufficient
Man^**^ vs. Ex | Unknown | NS | - | - | - | - | - | - | Insufficient
Man vs. PT | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man vs. PT | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Man vs. PT | Chronic | S | - | - | - | - | - | - | Insufficient
Man vs. PT | Chronic | NS | - | - | - | - | - | - | Insufficient
Man vs. PT | Mixed | S | - | - | - | - | - | - | Insufficient
Man vs. PT | Mixed | NS | - | - | - | - | - | - | Insufficient
Man vs. PT | Unknown | S | - | - | - | - | - | - | Insufficient
Man vs. PT | Unknown | NS | - | - | - | - | - | - | Insufficient
Man vs. Med | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man vs. Med | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Man vs. Med | Chronic | S | - | - | - | - | - | - | Insufficient
Man vs. Med | Chronic | NS | VAS: C51,140,329 | H | - | No | Direct | = > | Low
Man vs. Med | Chronic | NS | NDI: C51,140 | H | - | Yes | Direct | > SS | Low
Man vs. Med | Chronic | NS | % pain-free pts: C51 | H | - | NA | Indirect | > SS | Low
Man vs. Med | Mixed | S | - | - | - | - | - | - | Insufficient
Man vs. Med | Mixed | NS | - | - | - | - | - | - | Insufficient
Man vs. Med | Unknown | S | - | - | - | - | - | - | Insufficient
Man vs. Med | Unknown | NS | - | - | - | - | - | - | Insufficient
Man vs. Mob | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man vs. Mob | Acute/subacute | NS | VAS: B308 | M | - | NA | Direct | = S-NS | Low
Man vs. Mob | Chronic | S | - | - | - | - | - | - | Insufficient
Man vs. Mob | Chronic | NS | - | - | - | - | - | - | Insufficient
Man vs. Mob | Mixed | S | - | - | - | - | - | - | Insufficient
Man vs. Mob | Mixed | NS | VAS: B309,310 | M | - | Yes | Indirect | > SS | Low
Man vs. Mob | Mixed | NS | ROM (ext): B310 | M | - | NA | Indirect | > SS | Low
Man vs. Mob | Mixed | NS | VAS: D65 | M | - | NA | Direct | = S-NS | Low
Man vs. Mob | Mixed | NS | NDI: D65 | M | - | NA | Direct | = S-NS | Low
Man vs. Mob | Unknown | S | - | - | - | - | - | - | Insufficient
Man vs. Mob | Unknown | NS | - | - | - | - | - | - | Insufficient
Man vs. Ex | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man vs. Ex | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Man vs. Ex | Chronic | S | - | - | - | - | - | - | Insufficient
Man vs. Ex | Chronic | NS | - | - | - | - | - | - | Insufficient
Man vs. Ex | Mixed | S | - | - | - | - | - | - | Insufficient
Man vs. Ex | Mixed | NS | - | - | - | - | - | - | Insufficient
Man vs. Ex | Unknown | S | - | - | - | - | - | - | Insufficient
Man vs. Ex | Unknown | NS | - | - | - | - | - | - | Insufficient
Headache
Man vs. NoTx | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man vs. NoTx | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Man vs. NoTx | Chronic | S | - | - | - | - | - | - | Insufficient
Man vs. NoTx | Chronic | NS | - | - | - | - | - | - | Insufficient
Man vs. NoTx | Mixed | S | - | - | - | - | - | - | Insufficient
Man vs. NoTx | Mixed | NS | - | - | - | - | - | - | Insufficient
Man vs. NoTx | Unknown | S | - | - | - | - | - | - | Insufficient
Man vs. NoTx | Unknown | NS | - | - | - | - | - | - | Insufficient
Man vs. PL | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man vs. PL | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Man vs. PL | Chronic | S | - | - | - | - | - | - | Insufficient
Man vs. PL | Chronic | NS | ROM (ext, flx,rotation): B311 | L | - | NA | Indirect | > SS | Low
Man vs. PL | Mixed | S | - | - | - | - | - | - | Insufficient
Man vs. PL | Mixed | NS | - | - | - | - | - | - | Insufficient
Man vs. PL | Unknown | S | - | - | - | - | - | - | Insufficient
Man vs. PL | Unknown | NS | VAS: B, D333 | M | - | NA | Direct | = S-NS | Low
Man vs. PL | Unknown | NS | Pain duration (# of hours daily): B, D333 | M | - | NA | Direct | = S-NS | Low
Man vs. PL | Unknown | NS | Use of analgesics (# of tablets daily): B, D333 | M | - | NA | Indirect | = S-NS | Low
Man vs. Cold Packs | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man vs. Cold Packs | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Man vs. Cold Packs | Chronic | S | VAS: B334 | M | - | NA | Direct | > SS | Low
Man vs. Cold Packs | Chronic | S | VAS: C334 | M | - | NA | Direct | = S-NS | Low
Man vs. Cold Packs | Chronic | S | ROM (ext, fix): B, C334 | M | - | NA | Indirect | = S-NS | Low
Man vs. Cold Packs | Chronic | NS | - | - | - | - | - | - | Insufficient
Man vs. Cold Packs | Mixed | S | - | - | - | - | - | - | Insufficient
Man vs. Cold Packs | Mixed | NS | - | - | - | - | - | - | Insufficient
Man vs. Cold Packs | Unknown | S | - | - | - | | - | - | Insufficient
Man vs. Cold Packs | Unknown | NS | - | | - | - | - | - | Insufficient
Man vs. Mob | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man vs. Mob | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Man vs. Mob | Chronic | S | - | - | - | - | - | - | Insufficient
Man vs. Mob | Chronic | NS | - | - | - | - | - | - | Insufficient
Man vs. Mob | Mixed | S | - | - | - | - | - | - | Insufficient
Man vs. Mob | Mixed | NS | - | - | - | - | - | - | Insufficient
Man vs. Mob | Unknown | S | - | - | - | - | - | - | Insufficient
Man vs. Mob | Unknown | NS | - | - | - | - | - | - | Insufficient
Man vs. Ex | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man vs. Ex | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Man vs. Ex | Chronic | S | - | - | - | - | - | - | Insufficient
Man vs. Ex | Chronic | NS | - | - | - | - | - | - | Insufficient
Man vs. Ex | Mixed | S | - | - | - | - | - | - | Insufficient
Man vs. Ex | Mixed | NS | - | - | - | - | - | - | Insufficient
Man vs. Ex | Unknown | S | - | - | - | - | - | - | Insufficient
Man vs. Ex | Unknown | NS | - | - | - | - | - | - | Insufficient

S=specific; NS=nonspecific; SS=statistically significant; S-NS=statistically nonsignificant; Man=manipulation; Acu=acupuncture; Ma=massage; Mob=mobilization; PL=placebo; Tx=treatment. Med=medication(s); Int=intervention; PT=physiotherapy; ST=standard therapy; E-acu=electro-acupuncture; MR=muscle relaxation; TENS= transcutaneous electrical nerve stimulation; Ex=exercise; TrP=trigger point; VAS=visual analog scale; RMDQ=Roland Morris Disability scale; NHP=Nottingham Health Profile; PPT= pressure pain threshold; HFAQ=Hanover functional ability questionnaire; MPQ=McGill pain questionnaire; ext=extension; flx=flexion; rot=rotation; PDI=pain disability index; min=minute(s); hr(s)=hour(s); L=low; M=medium; H=high; pt(s)=patient(s); SF=short-form; NPQ=neck pain questionnaire; GWBS=global well-being scale; SLR=straight leg raising; GPE= Global perceived effect; NSAIDS=nonsteroidal antiinflammatory drugs; FTF=finger-to-floor; SF-PQ=short form pain questionnaire; PRI=pain rating index; PPI=present pain intensity; NA=not applicable

^ψ^ Grade (High, moderate, low, and insufficient)

> Favors treatment A over treatment B

< Favors treatment B over treatment A

><, =>, <= Inconsistent beneficial effect

H = high

L = low

M = medium

- No evidence

^**^ Manipulation in combination with mobilization

B = immediate post-treatment

C = short-term post-treatment

D = intermediate-term post-treatment

E = long-term post-treatment

= Similar beneficial effect

Population with acute/subacute pain. In total, there were four trials eligible for this section, all of which enrolled patients with nonspecific pain.308,314,315,322

Subjects with specific pain.

Manipulation versus placebo. No relevant studies were identified.

Manipulation versus no treatment. No relevant studies were identified.

Manipulation versus another type/method of the same CAM. No relevant studies were identified.

Manipulation versus other treatments. No relevant studies were identified.

Manipulation versus medication. No relevant studies were identified.

Manipulation + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Manipulation versus placebo. In one trial,314 immediate post single treatment mean VAS scores indicated statistically significantly lower degree of pain in patients receiving ipsilateral manipulation compared to placebo ultrasound (23.6 ± 18.6 versus 46.5 ± 21.8, p = 0.001). There was no difference between the applications of contralateral manipulation and placebo in lowering pain intensity (p = 0.93).314 Manipulation was administered by chiropractors.

In another trial,308 manipulation delivered by trained chiropractors resulted in significantly lower pain intensity (VAS) compared with placebo (light hand placement on the side of neck without application of any side-different pressure or tension) immediately after the treatment (p = 0.01).

Manipulation versus no treatment. No relevant studies were identified.

Manipulation versus mobilization. In one trial,308 the post-treatment mean VAS scores were not statistically significantly different between the patients randomized to manipulation and those randomized to mobilization (p = 0.16; no other numerical data were reported).

Manipulation (type 1) versus manipulation (type 2). In one trial,314 the application of ipsilateral manipulation led to a lower intensity of pain on VAS compared to contralateral manipulation (41.4 ± 28.4, p = 0.0005).

Immediate post-treatment results of another trial indicated that spinal manipulation did not differ from manipulation with mechanically-assisted device (VAS: 21.8 ± 21.4 versus 20.4 ± 18.4, respectively, p = 0.77).315 Both treatments were performed by experienced chiropractors.315

Manipulation versus other treatments. No relevant studies were identified.

Manipulation versus medication. No relevant studies were identified.

Manipulation + other treatments versus the same other treatments. In one trial,322 patients randomized to receive a combination of thoracic spine manipulation and electro-thermal therapy compared to those randomized to electro-thermal therapy alone, experienced greater short-term post-treatment mean improvements in pain – VAS score (between-group mean score difference: 26.5, 95 percent CI: 22.9, 30.2) and disability – the Northwick Neck Pain Questionnaire (NPQ) (between-group mean score difference: 8.8, 95 percent CI: 7.5, 10.1). The treatments were performed by an experienced manual therapist.

Population with chronic pain. A total of eight trials were included in this section.51,140,311,316,317,326,328,329 All trials enrolled patients with nonspecific chronic neck pain. In four of these trials, the treatment of cervicogenic headaches was the primary goal.311,316,317,328

Subjects with specific pain.

Manipulation versus placebo. No relevant studies were identified.

Manipulation versus no treatment. No relevant studies were identified.

Manipulation versus another type/method of the same CAM. No relevant studies were identified.

Manipulation versus other treatments. No relevant studies were identified.

Manipulation versus medication. No relevant studies were identified.

Manipulation + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Manipulation versus placebo. In two studies, it was demonstrated that patients randomized to manipulation experienced significantly greater immediate post-treatment reduction in pain (measured on VAS, PPT)326,330 and disability (measured on NDI)326 compared to patients randomized to placebo (hand maneuver without high velocity thrust in patients naïve to spinal manipulation,326 and sham ultrasound330). Treatments consisted of a single thoracic manipulation by physical therapists in one trial,326 and five cervical osteopathic interventions over a 10 week period in the other trial.330 In one trial,311 the use of cervical manipulation performed by a trained chiropractor was associated with significant increase in cervical ROM (extension, flexion, rotation) compared to sham manipulation for cervicogenic headache.311

Manipulation versus no treatment. No relevant studies were identified.

Manipulation versus mobilization. No relevant studies were identified.

Manipulation (type 1) versus manipulation (type 2). One dose-response study,328 showed significantly better response in headache-related pain intensity (VAS score) and disability (Modified Von Korff scale) with a higher dose of manipulation (three to four chiropractor visits per week for 3 weeks) compared to one chiropractor visit (per week for 3 weeks) in short-term followup.

Manipulation versus another type/method of the same CAM. No relevant studies were identified.

Manipulation versus other treatments. In one trial,316 there was a significant improvement in pain intensity in the manipulation group versus TENS group (2.81 ± 1.15 versus 5.26 ± 1.83).316 Both groups improved in pain intensity and ROM compared to baseline but there was no difference in post treatment scores between the groups in ROM measures (1.17 ± 0.86 versus 1.43 ± 1.04).

Another trial,317 compared the effect of 3 weeks treatment with manipulation by registered chiropractors to that of low level laser and massage in patient with cervicogenic headaches. In this trial, the use of analgesics decreased by 36 percent in the manipulation group but was not changed in massage group. This difference was statistically significant (P = 0.04). This study also reported significantly greater improvement in number of headache hours per day in the manipulation group versus soft tissue massage group (decrease of 69 percent versus 37 percent, p = 0.03).317

Manipulation versus medication. In one trial,329 although both manipulation (performed by a trained rheumatologist) and medication groups demonstrated improvement on mean VAS at 3 weeks (5.0 ± 3.2 versus 1.8 ± 3.1, P = 0.20), there was no significant difference between manipulation and medication (Diazepam) in short-term post-treatment reduction of pain (VAS). In contrast, findings from two other trials,51,140 indicated a significant superiority of manipulation performed by experienced chiropractors over medication (e.g., NSAIDs, Celebrex, Vioxx, Paracetamol) in reducing immediate/short-term post-treatment pain intensity and disability (Oswestry scale, NDI).51,140 In one of these trials,51 the proportion of pain-free patients after the treatment was significantly higher in the manipulation group compared to the medication group (27.3 percent versus 5.0 percent, p = 0.05).

Manipulation + other treatments versus the same other treatments. No relevant studies were identified.

Population with mixed duration of pain. This section included eight trials.65,306,309,310,312,321,323,327 All except for one trial included subjects with nonspecific pain.321

Subjects with specific pain.

Manipulation versus placebo. No relevant studies were identified.

Manipulation versus no treatment. No relevant studies were identified.

Manipulation versus another type/method of the same CAM. No relevant studies were identified.

Manipulation versus other treatments. No relevant studies were identified.

Manipulation versus medication. No relevant studies were identified.

Manipulation + other treatments versus the same other treatments. In one trial,321 patients with whiplash injuries receiving manipulation of thoracic spine (performed twice in combination with physiotherapy on the 5^th^ and 10^th^ sessions) had significantly greater mean reduction in pain score (VAS) at immediate/short-term post-treatment followup compared to patients treated with physiotherapy alone which consisted of active exercise, electrotherapy, ultrasound, and manual therapy (2.27 ± 0.87 versus 1.66 ± 0.91, p = 0.002).

Subjects with nonspecific pain.

Manipulation versus placebo. In one trial,312 patients randomized to a single cervical manipulation experienced significantly greater immediate post-treatment percent increase (40.0 percent-55.0 percent) in pressure pain threshold (PPT) around fixation level of 4 tender points compared to placebo (0-0.8 percent, p < 0.0001). In another trial,310 spinal manipulation was more effective than sham treatment in patients with mechanical neck pain in improving pain (VAS) and cervical ROM.

Manipulation versus no treatment. No relevant studies were identified.

Manipulation versus mobilization. Results regarding the comparison of manipulation and mobilization in terms of improvement in pain and disability were reported for 3 trials and were inconsistent.65,309,310 For example, in one trial in 100 patients with unilateral mechanical pain, manipulation was found to be more effective (nonsignificant) than mobilization in immediate post-treatment improvement in pain intensity (NRS-101, VAS).309 In a larger trial (336 patients),65 the intermediate-term post-treatment differences between the groups of manipulation and mobilization were clinically negligible and statistically nonsignificant with respect to pain intensity (NRS-11: -0.02, 95 percent CI: -0.69, 0.65) and disability (NDI: 0.46, 95 percent CI: -0.89, 1.82).

In one trial, comparing two different modalities of the combined treatment of manipulation and mobilization (thrust versus nonthrust), thrust manipulation/ mobilization group achieved greater short-term post-treatment improvements in disability (between-group mean NDI score difference: 10.03, 95 percent CI: 5.3, 14.7) and pain intensity (between-group mean Numeric Pain Rating Scale score difference: 2.03, 95 percent CI: 1.4, 2.7) compared to nonthrust manipulation/mobilization group of patients.306

Manipulation (type 1) versus manipulation (type 2). The effectiveness of manipulation based on endplay assessment and manipulation determined by sham was compared in one trial.327 The between-group differences in immediate/short-term post-treatment pain (NRS, McGill Pain Questionnaire or MPQ, VAS, PPT) and disability (NDI) were statistically nonsignificant.

Manipulation versus other treatments. No relevant studies were identified.

Manipulation versus medication. No relevant studies were identified.

Manipulation + other treatments versus the same other treatments. No relevant studies were identified.

Manipulation versus manipulation + other treatment. In one small trial323 of 6 subjects randomized to receive either manipulation alone or in combination with postisometric relaxation, no meaningful results were obtained regarding the between-group differences in immediate post-treatment disability (NDI score) or pain intensity (VAS score) due to small sample size. The manipulation alone group had a numerical favor over the combination group.

Population with unknown duration of pain. This section included six trials comprising of patients with neck pain of unknown duration.307,313,318-320,324,325 One of these trials enrolled patients with specific pain (facet syndrome, whiplash injury)319,320 and the remaining five trials – patients with nonspecific neck pain.307,313,318,324,325

Subjects with specific pain.

Manipulation versus placebo. No relevant studies were identified.

Manipulation versus no treatment. No relevant studies were identified.

Manipulation (type 1) versus manipulation (type 2). In one trial of 30 patients with facet syndrome,319 two approaches of manipulation (i.e., top segment adjustment in the direction of the restriction versus top and bottom segment adjustments in the direction of the restriction and the opposite direction, respectively) were compared in terms of short-term post-treatment reduction in pain intensity (NRS-101, MPQ-short form) and disability (NDI). Both groups had significantly improved pain and disability measures. The only between-group difference was observed for cervical forward flexion ROM in favor of the top and bottom segment adjustment technique.

Manipulation versus other treatments. No relevant studies were identified.

Manipulation versus medication. No relevant studies were identified.

Manipulation + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Manipulation versus placebo. In one trial,325 manipulation was compared to placebo with respect to immediate-term post-treatment reduction in pain intensity (VAS). In this trial, patients who received manipulation had a significantly greater mean reduction in VAS scores (15.5, 95 percent CI: 11.8, 19.2) than those who received placebo (4.2, 95 percent CI: 1.9, 6.6).

Manipulation versus no treatment. In one trial,324 manipulation groups had a modest improvement in cervical ROM or pain (VAS) compared to no treatment group. There was no significant difference between the manipulation and no treatment groups in immediate-term post-treatment pain intensity during left and right cervical rotation.324

Manipulation (type 1) versus manipulation (type 2). In three trials,307,313,318 two different modalities of manipulation were compared. In the first trial,318 there was no significant difference in post-treatment pain (MPQ-short form, NRS-101), disability (NDI), or ROM between the two approaches of manipulation (cervical versus cervical/thoracic). In the second trial313 there was a modest advantage in improving muscle strength (in pounds) for manipulation applied in the upper and lower spine compared to that applied only in the lower spine (19.6 ± 6.5 versus 15.5 ± 6.4, p = 0.05). The third study reported similar beneficial effect of cervical rotatory manipulation compared to supine lateral break manipulation in immediate and short-term post-treatment followup for pain intensity and disability (NRS, MPQ-short-form, and NDI), and cervical ROM.307

Manipulation versus other treatments. No relevant studies were identified.

Manipulation versus medication. No relevant studies were identified.

Manipulation + other treatments versus the same other treatments. No relevant studies were identified.

#### 7 Manipulation + Mobilization for Treatment of Neck Pain

Two studies were included in this section, both of which were reported in multiple publications (Table 3).

Population/trial characteristics. These studies were conducted in the Netherlands85 and Australia.81 The proportion of females was greater (70 percent of all patients) for the Australian study.81 The treatment duration was 6 weeks in both trials.

Manual therapy in these trials were compared with exercise, physiotherapy, and no treatment.

Risk of bias. Both trials had fair risk of bias (i.e., scored two out of four on treatment allocation concealment, balance of baseline characteristics between the groups, patients’ blinding status, and reasons/number of dropouts/withdrawals).

Efficacy. A summary of the key results is presented in Table 14. For further detail of the trials please see the evidence tables. (Appendix C, table 2.9 – table 2.16)

Population with acute/ subacute pain. No relevant studies were identified (see one study85 in the Population with Chronic Pain sub-section).

##### Population with chronic pain

Subjects with specific pain. No relevant studies were identified.

Subjects with nonspecific pain.

Manual therapy versus placebo. No relevant studies were identified.

Manual therapy versus no treatment. No relevant studies were identified.

Manual therapy versus medication. No relevant studies were identified

Manual therapy versus other treatments. In the first trial,85the use of manual therapy (spinal manipulation + mobilization) led to a significantly greater improvement in the main complaint (pain, and/or physical functioning measured by a 10-point scale) when compared to physiotherapy (exercise, massage, heat, electrotherapy, ultrasound, shortwave diathermy) in patients with chronic or sub-acute nonspecific neck pain. The mean difference in physical functioning at 12 weeks followup between physiotherapy and manual therapy while adjusting for baseline differences was 1.9. The unadjusted mean improvements from baseline in physical functioning at 12 weeks for the manual therapy and physiotherapy groups were 4.8 and 3.4, respectively. The mean changes in cervical ROM (forward flexion, lateral flexion, extension) between the groups ranged from zero to five degrees which were neither clinically meaningful nor statistically significant. The long-term results (12 months post-treatment)85,87 were reported for the combined sample of subjects with low back and neck pain and therefore are not presented in this review.

In the second trial,81,83 spinal manipulation plus mobilization with or without exercise (low load endurance exercises aimed to train muscle control of the cervico-scapular region) and exercise alone did not differ in the degree of reducing headache frequency (average number of headache days per week), intensity (VAS score: 0-10) and neck pain (percentage of patients who improved ≥ 50 percent on a 10 point pain rating scale calculated from MPQ). However, all three active treatments were significantly better in reducing pain intensity and the frequency of headache than the control (i.e., no treatment) group (p < 0.001). In all active treatment groups, the median daily medication intake (Anatomical Therapeutic Chemical code) at 12 months post-treatment were significantly decreased (93 percent - 100 percent) compared to baseline. In contrast, the daily median medication intake in the no active treatment group increased by 33.0 percent compared to baseline (p < 0.015).

Population with mixed duration of pain. No relevant studies were identified.

Population with unknown duration of pain. No relevant studies were identified.

#### 8 Manipulation for Treatment of Thoracic Pain

Only one trial335 was identified and included in this section. In this trial, 30 subjects with nonspecific thoracic pain of unknown duration were randomized to receive either manipulation or placebo (nonfunctional ultrasound) for 3 weeks. The outcomes of interest, assessed immediately or short-term (1 month) after the end of treatment were ROM of the thoracic spine (flexion, extension, rotation) and pain threshold. The study authors also assessed subjective measures of pain intensity (VAS, MPQ) and disability (Oswestry).

Population/trial characteristics. This trial was conducted in the United Kingdom. The participants were men (47 percent) and women 16 – 55 years old. Half of study participants were 16 – 24 years old. Thoracic pain was located in mid section of thorax (T5 – T9) in 77 percent, and upper (T1 – T4) and lower sections (T10 – T12) of the thoracic spine in the remaining 23.0 percent. The intervention consisted of thoracic spine manipulation (n = 15) and the control consisted of nonfunctional ultrasound application which the study considered as placebo treatment (n = 15). The patients received treatment until they were free of symptoms or up to a maximum of 6 treatments during a minimum period of 2 weeks to a maximum period of 3 weeks with two to three treatments per week. A followup consultation for reassessment took place 1 month after the final treatment.

Risk of bias. This trial was rated as high risk of bias. Neither randomization nor treatment allocation concealment could be ascertained. The care provider and outcome assessors were not blinded to the intervention. The dropout rates were not reported either.

Efficacy. Please seeTable 15 for the key efficacy results. Immediately after the end of treatment, there were statistically significant differences for right and left lateral flexion measures, between the manipulation and placebo groups, in favor of manipulation (p < 0.025). After 1 month of followup, the between-group differences for all the ROM measures were not statistically significant at α = 0.025 (p > 0.025). The immediate post-treatment mean pain score (VAS) was significantly lower in the manipulation versus placebo group (21.9 ± 11.4 versus 35.6 ± 14.2, p = 0.014). Meanwhile, pain and disability scores of MPQ and Oswestry scales were not significantly different between the two groups of subjects. At 1 month of followup, only pain measured on MPQ was significantly lower in the manipulation versus placebo group (0.08 ± 0.18 versus 0.13 ± 0.11, p = 0.03).

Table 15 Key Results – Manipulation therapy for thoracic pain

CAM therapy | Duration of pain | Cause of pain | Outcome | Risk-of-bias | Precision of the pooled estimate | Consistency | Directness | Finding | GRADE^ψ^
Man vs. PL | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Man vs. PL | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Man vs. PL | Chronic | S | - | - | - | - | - | - | Insufficient
Man vs. PL | Chronic | NS | - | - | - | - | - | - | Insufficient
Man vs. PL | Mixed | S | - | - | - | - | - | - | Insufficient
Man vs. PL | Mixed | NS | - | - | - | - | - | - | Insufficient
Man vs. PL | Unknown | S | - | - | - | - | - | - | Insufficient
Man vs. PL | Unknown | NS | VAS: B335 | H | - | NA | Direct | > SS | Low
Man vs. PL | Unknown | NS | MPQ: B335 | H | - | NA | Direct | = S-NS | Low
Man vs. PL | Unknown | NS | MPQ: C335 | H | - | NA | Direct | > SS | Low
Man vs. PL | Unknown | NS | Oswestry: B335 | H | - | NA | Direct | = S-NS | Low
Man vs. PL | Unknown | NS | ROM (right/left lateral flx): B335 | H | - | NA | Indirect | > SS | Low
Man vs. PL | Unknown | NS | ROM (flx, ext, rotation): C335 | H | - | NA | Indirect | = S-NS | Low

S=specific; NS=nonspecific; SS=statistically significant; S-NS=statistically nonsignificant; Man=manipulation; Acu=acupuncture; Ma=massage; Mob=mobilization; PL=placebo; Tx=treatment. Med=medication(s); Int=intervention; PT=physiotherapy; ST=standard therapy; E-acu=electro-acupuncture; MR=muscle relaxation; TENS= transcutaneous electrical nerve stimulation; Ex=exercise; TrP=trigger point; VAS=visual analog scale; RMDQ=Roland Morris Disability scale; NHP=Nottingham Health Profile; PPT= pressure pain threshold; HFAQ=Hanover functional ability questionnaire; MPQ=McGill pain questionnaire; ext=extension; flx=flexion; rot=rotation; PDI=pain disability index; min=minute(s); hr(s)=hour(s); L=low; M=medium; H=high; pt(s)=patient(s); SF=short-form; NPQ=neck pain questionnaire; GWBS=global well-being scale; SLR=straight leg raising; GPE= Global perceived effect; NSAIDS=nonsteroidal antiinflammatory drugs; FTF=finger-to-floor; SF-PQ=short form pain questionnaire; PRI=pain rating index; PPI=present pain intensity; NA=not applicable

^ψ^ Grade (High, moderate, low, and insufficient)

B = immediate post-treatment

C = short-term post-treatment

D = intermediate-term post-treatment

E = long-term post-treatment

H = high

L = low

M = medium

- No evidence

= Similar beneficial effect

> Favors treatment A over treatment B

< Favors treatment B over treatment A

><, =>, <= Inconsistent beneficial effect

#### 9 Mobilization for Treatment of Low Back Pain

This section included 18 trials. One trial was reported in two publications (Table 3)

Population/trial characteristics. The studies were conducted in Australia (three),336-338Canada (one),279, Bulgaria (one),339 China (one),340 Finland (four),341-344 Spain (one),345, Sweden (one),346 Thailand (one),347 United Kingdom, (one)348 and United States (four).55,349-351

The proportion of men and women was similar in nine studies,55,336,338-341,343,344,348 and differed (> 60.0 percent men or women) in six trials.279,337,345,347,350,351 Two studies included either only women346 or only men.349 Information on gender was not reported for one study.342

The trials recruited adults with the mean age ranging from about 20.0 years349 to 47.0 years.336 Table 16 presents the control interventions in the included studies.

Table 16 Mobilization for treatment of low back pain- Control interventions

Type of control group | Cause of Pain | N studies | Detail of Control intervention
1 – Inactive treatments
Placebo/sham | Non Specific | 2 | Comfortable positioning of patients without physical contact ,348sham mobilization339
Placebo/sham | Specific | 1 | Manual transverse frictions on the gluteus medius muscles346
No treatment | Non Specific | 3 | Control without any manual or physical treatments337,345,349
No treatment | Specific | 0 | NA
2 – Active treatments
Exercise/physical activity | Non Specific | 3 | Rhythmical bending of lumbar spine and stretching,342press up maneuver in prone position ,350home exercise with specific instruction by physiotherapist344
Exercise/physical activity | Specific | 1 | Low-tech exercise consist of McKenzie technique and spinal stabilization exercises,351high-tech exercise consist of cardiovascular, isotonic and isokinetic exercise351
Physiotherapy | Nonspecific | 4 | massage, therapeutic stretching, trunk stabilization exercise, exercise therapy,341manual, thermal, and electrotherapies according to the Finnish routine, massage, specific mobilizations, and manual traction, stretching342massage, therapeutic stretching and exercise therapy,343manual therapy without thrusts, thermal, electrotherapy344
Physiotherapy | Specific | 0 | NA
Traction | Nonspecific | 1 | Traction with sham mobilization,339
Traction | Specific | 0 | NA
Physical modalities | Nonspecific | 1 | Sinous-modulated current therapy and sham mobilization,339
Physical modalities | Specific | 1 | Hot-pack, ultrasound, TENS,351
Manual therapy | Nonspecific | 3 | Spinal manipulation,55,279massage347
Manual therapy | Specific | 1 | Massage340
Other technique of spinal mobilization | Nonspecific | 1 | Postero-anterior mobilization at the most symptomatic lumbar spine (vs. same technique at randomly selected lumbar level)338
| Specific | 0 | NA

NA= not applicable

The number of treatments used in 10 studies ranged from one279,336-338,345,347,349,350 to five sessions.341,343 In three studies, up to 10^342,344^ or 12 sessions,339 and in one study351 – 24 treatments sessions were provided. This information was not clearly reported for four studies.55,340,346,348

Risk of bias. The risk-of-bias graph for the trials included in this sub-section is presented in Figure 31. All trials were randomized. The adequate method of randomization and treatment allocation concealment was reported for 38 percent and 19 percent of the trials, respectively. Only about half of the trials reported that distribution of the subjects’ baseline characteristics across the treatment arms was similar. In 69.0 percent of the trials, study participants were not blinded to the treatment. Up to 63.0 percent of the trials reported acceptable dropout rate. Results based on intention-to-treat analysis were explicitly reported for 31.0 percent of the trials. The data for selected items of the risk of bias tool across the CAM interventions (acupuncture; spinal manipulation; spinal mobilization; combination of manipulation and mobilization; and massage therapy) is displayed in table 7.1 of Appendix G.

Figure 31 Risk of bias scores (%)

Figure 31 depicts the Risk of bias scores percents as a bar graph. On the left hand side are listed, vertically, Q1 through Q13. A horizontal solid black line represents Yes, a gray line, No, and a dotted line, Unclear. At the bottom, left to right, are the percentages 0%, 20%, 40%, 60% 80%, and 100%. Q1 is Yes 0 to about 40%. No about 40% to about 50% Unclear about 50% to 100%. Q2 is Yes 0 to about 20%, No about 20% to just under 40%, Unclear, just under 40% to 100%. Q3 is Yes 0% to about 45%, No about 45% to about 50%, and Unclear about 50% to 100%. Q4 is Yes 0% to 10%, No 10% to about 90%, and Unclear about 90% to 100%. Q5 is No 0 to about 85%, and Unclear about 85% to 100%. Q6 is Yes 0 to about 70%, Unclear about 70% to 100%. Q7 is Yes 0% to about 30%, No about 30% to just under 40%, Unclear just under 40% to 100%. Q8 is Yes 0% to about 45%, No about 45% to about 55%, and Unclear about 55% to 100%. Q9 is Yes 0 to just over 65%, No just over 65% to 80%, Unclear 80% to 100%. Q10 is Yes 0 to 100%. Q11 is Yes 0% to about 55%, No about 55% to 40%, and Unclear 40% to 100%. Q12 is Yes 0% to 70%, No about 70% to about 80%, and Unclear about 80% to 100%. Q13 is Yes 0 to about 7%, No about 7% to about 35%, and Unclear about 35% to 100%.

Efficacy results. A summary of the key results is presented in Table 17. For further detail of the trials please see the evidence tables. (Appendix C, table 1.17 – table 1.20)

Table 17 Key results – Mobilization therapy for low back pain

CAM therapy | Duration of pain | Cause of pain | Outcome | Risk-of-bias | Precision of the pooled estimate | Consistency | Directness | Finding | GRADE^ψ^
Mob vs. No Tx | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Mob vs. No Tx | Acute/subacute | NS | VAS: B, C349 | H | - | NA | | > SS | Low
Mob vs. No Tx | Acute/subacute | NS | MPQ: B, C349 | H | - | NA | Direct | > SS | Low
Mob vs. No Tx | Chronic | S | Oswestry: B, C351 | H | - | NA | Direct | = S-NS | Low
Mob vs. No Tx | Chronic | NS | VAS: B345 | M | - | NA | Direct | > SS | Low
Mob vs. No Tx | Chronic | NS | ROM (right and left side bending): B345 | M | - | NA | Indirect | > SS | Low
Mob vs. No Tx | Chronic | NS | RMDQ: B345 | M | - | NA | Direct | > SS | Low
Mob vs. No Tx | Mixed | S | - | - | - | - | - | - | Insufficient
Mob vs. No Tx | Mixed | NS | VAS: B, C337 | H | - | NA | Direct | = S-NS | Low
Mob vs. No Tx | Mixed | NS | ROM (flx, ext, FTF): B, C337 | H | - | NA | Indirect | = S-NS | Low
Mob vs. No Tx | Unknown | S | - | - | - | - | - | - | Insufficient
Mob vs. No Tx | Unknown | NS | - | - | - | - | - | - | Insufficient
Mob vs. PL | Acute/subacute | S | VAS: B346 | H | - | NA | Direct | = S-NS | Low
Mob vs. PL | Acute/subacute | S | ROM (flx, ext): B346 | H | - | NA | Indirect | = S-NS | Low
Mob vs. PL | Acute/subacute | S | % pts using analgesics: B346 | H | - | NA | Indirect | > SS | Low
Mob vs. PL | Acute/subacute | S | Median duration of sick leave: B346 | H | - | NA | Indirect | > SS | Low
Mob vs. PL | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Mob vs. PL | Chronic | S | - | - | - | - | - | - | Insufficient
Mob vs. PL | Chronic | NS | - | - | - | - | - | - | Insufficient
Mob vs. PL | Mixed | S | - | - | - | - | - | - | Insufficient
Mob vs. PL | Mixed | NS | VAS: B, C348 | M | - | NA | Direct | = S-NS | Low
Mob vs. PL | Mixed | NS | ROM (ext, FTF): B, C348 | M | - | NA | Indirect | = S-NS | Low
Mob vs. PL | Mixed | NS | ROM (full and total flx): B348 | M | - | NA | Indirect | > SS | Low
Mob vs. PL | Unknown | S | - | - | - | - | - | - | Insufficient
Mob vs. PL | Unknown | NS | - | - | - | - | - | - | Insufficient
Mob vs. PT | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Mob vs. PT | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Mob vs. PT | Chronic | S | Oswestry: B, C351 | H | - | NA | Direct | = S-NS | Low
Mob vs. PT | Chronic | NS | VAS: B | M | Precise (2)^£^341,343 | No | Direct | > SS | Low
Mob vs. PT | Chronic | NS | Oswestry: B | M | Precise (2)341,343 | Yes | Direct | > SS | Moderate
Mob vs. PT | Chronic | NS | FTF: B | M | Precise (2)341,343 | Yes | Direct | = S-NS | Moderate
Mob vs. PT | Chronic | NS | VAS: B, D344 | H | - | NA | Direct | = S-NS | Low
Mob vs. PT | Chronic | NS | ROM (modified Schober test): B, D344 | H | - | NA | Indirect | = S-NS | Low
Mob vs. PT | Chronic | NS | SLR (degrees): B, D344 | H | - | NA | Indirect | = S-NS | Low
Mob vs. PT | Chronic | NS | ROM (ext; in degrees): B, D344 | H | - | NA | Indirect | = S-NS | Low
Mob vs. PT | Mixed | S | - | - | - | - | - | - | Insufficient
Mob vs. PT | Mixed | NS | Oswestry: B342 | M | - | NA | Direct | = S-NS | Low
Mob vs. PT | Mixed | NS | Oswestry: D342 | M | - | NA | Direct | > SS | Low
Mob vs. PT | Mixed | NS | # of sick leave days: B, C, D342 | M | - | NA | Indirect | = S-NS | Low
Mob vs. PT | Unknown | S | - | - | - | - | - | - | Insufficient
Mob vs. PT | Unknown | NS | - | - | - | - | - | - | Insufficient
Mob vs. Man | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Mob vs. Man | Acute/subacute | NS | RMDQ: B55 | M | - | NA | Direct | < SS | Low
Mob vs. Man | Chronic | S | - | - | - | - | - | - | Insufficient
Mob vs. Man | Chronic | NS | PPT: B279 | M | - | NA | Direct | = S-NS | Low
Mob vs. Man | Mixed | S | - | - | - | - | - | - | Insufficient
Mob vs. Man | Mixed | NS | - | - | - | - | - | - | Insufficient
Mob vs. Man | Unknown | S | - | - | - | - | - | - | Insufficient
Mob vs. Man | Unknown | NS | - | - | - | - | - | - | Insufficient
Mob vs. Ma | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Mob vs. Ma | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Mob vs. Ma | Chronic | S | - | - | - | - | - | - | Insufficient
Mob vs. Ma | Chronic | NS | VAS: B347 | H | - | NA | Direct | < SS | Low
Mob vs. Ma | Mixed | S | - | - | - | - | - | - | Insufficient
Mob vs. Ma | Mixed | NS | - | - | - | - | - | - | Insufficient
Mob vs. Ma | Unknown | S | VAS: B340 | H | - | NA | Direct | = S-NS | Low
Mob vs. Ma | Unknown | NS | - | - | - | - | - | - | Insufficient
Mob vs. Ex | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Mob vs. Ex | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Mob vs. Ex | Chronic | S | - | - | - | - | - | - | Insufficient
Mob vs. Ex | Chronic | NS | ROM (modified Schober test): B, D344 | H | - | NA | Indirect | = S-NS | Low
Mob vs. Ex | Chronic | NS | SLR (degrees): B, D344 | H | - | NA | Indirect | = S-NS | Low
Mob vs. Ex | Chronic | NS | ROM (ext; in degrees): B, D344 | H | - | NA | Indirect | = S-NS | Low
Mob vs. Ex | Mixed | S | - | - | - | - | - | - | Insufficient
Mob vs. Ex | Mixed | NS | VAS: B350 | H | - | NA | Direct | = S-NS | Low
Mob vs. Ex | Mixed | NS | ROM (ext): B350 | H | - | NA | Indirect | = S-NS | Low
Mob vs. Ex | Mixed | NS | Oswestry: B342 | M | - | NA | Direct | = S-NS | Low
Mob vs. Ex | Unknown | S | - | - | - | - | - | - | Insufficient
Mob vs. Ex | Unknown | NS | - | - | - | - | - | - | Insufficient

S=specific; NS=nonspecific; SS=statistically significant; S-NS=statistically nonsignificant; Man=manipulation; Acu=acupuncture; Ma=massage; Mob=mobilization; PL=placebo; Tx=treatment. Med=medication(s); Int=intervention; PT=physiotherapy; ST=standard therapy; E-acu=electro-acupuncture; MR=muscle relaxation; TENS= transcutaneous electrical nerve stimulation; Ex=exercise; TrP=trigger point; VAS=visual analog scale; RMDQ=Roland Morris Disability scale; NHP=Nottingham Health Profile; PPT= pressure pain threshold; HFAQ=Hanover functional ability questionnaire; MPQ=McGill pain questionnaire; ext=extension; flx=flexion; rot=rotation; PDI=pain disability index; min=minute(s); hr(s)=hour(s); L=low; M=medium; H=high; pt(s)=patient(s); SF=short-form; NPQ=neck pain questionnaire; GWBS=global well-being scale; SLR=straight leg raising; GPE= Global perceived effect; NSAIDS=nonsteroidal antiinflammatory drugs; FTF=finger-to-floor; SF-PQ=short form pain questionnaire; PRI=pain rating index; PPI=present pain intensity; NA=not applicable

^ψ^ Grade (High, moderate, low, and insufficient)

^£^ Number of pooled trials

B = immediate post-treatment

C = short-term post-treatment

D = intermediate-term post-treatment

E = long-term post-treatment

H = high

L = low

M = medium

- No evidence

= Similar beneficial effect

> Favors treatment A over treatment B

< Favors treatment B over treatment A

><, =>, <= Inconsistent beneficial effect

Population with acute/subacute pain. There were four trials, of which, three trials studied subjects with nonspecific pain55,339,349 and one – subjects with cause-specific pain (i.e., pelvic joint dysfunction.346

Subjects with specific pain.

Mobilization versus placebo. In one trial,346 consisting of mostly women (96.0 percent) affected by sacroiliac joint dysfunction, there was no statistically significant difference in post-treatment pain intensity and lumbar mobility between subjects in the mobilization and placebo (massage therapy consisting of manual transverse frictions of the gluteus medius muscle) groups. The median number of analgesic pills taken was significantly higher in the placebo group (median: 3.5, range: 0-54) compared to mobilization group (median: 0, range: 0-132). The median duration of sick leave (in days) was also significantly greater in the placebo (median: 14, range: 0-26) versus mobilization group (median: 7, range: 0-35).

Mobilization versus no treatment. No relevant studies were identified.

Mobilization versus another type/method of the same CAM. No relevant studies were identified.

Mobilization versus other treatments. No relevant studies were identified.

Mobilization versus medication. No relevant studies were identified.

Mobilization + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Mobilization versus placebo. No relevant studies were identified.

Mobilization versus no treatment. In one trial,349 mobilization was compared to no treatment in post-treatment pain and disability. Immediately or short-term after the end of treatment, mobilization group had significantly lower pain scores (VAS, MPQ; p = 0.001) compared to ‘no treatment’ group.

Mobilization versus another type/method of the same CAM. No relevant studies were identified.

Mobilization versus other treatments.

In one trial,339 immediate or intermediate-term post-treatment pain intensity was significantly lower in the mobilization group compared to electro-stimulation, traction, or medication group.

Mobilization versus medication. No relevant studies were identified.

Mobilization + other treatments versus the same other treatments. No relevant studies were identified.

Mobilization versus manipulation. In one trial,55 2 weeks after the randomization, the manipulation group of subjects had a significantly better disability score (RMDQ) compared to the mobilization group.

Population with chronic pain. Seven trials were included in this sub-section,.279,341,343-345,347,351 Of these, six trials studied subjects with nonspecific LBP and one trial included postlaminectomy patients.351

Subjects with specific pain.

Mobilization versus placebo. No relevant studies were identified.

Mobilization versus no treatment. Immediate and short-term post-treatment degree of disability (Oswestry score) did not differ between the mobilization and no treatment groups.351

Mobilization versus another type/method of the same CAM. No relevant studies were identified.

Mobilization versus other treatments. Immediate and short-term post-treatment degree of disability (Oswestry score) did not differ between the subjects who received mobilization and physiotherapy (physical modalities including exercise).351

Mobilization versus medication. No relevant studies were identified.

Mobilization + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Mobilization versus placebo. No relevant studies were identified.

Mobilization versus no treatment. Kaltenborn’s wedge assisted posteroanterior mobilization was shown to be significantly superior to ‘no treatment’ in improving pain (VAS: p < 0.001), back bending mobility (right side: p < 0.004, left side: p < 0.02), and disability (RMDQ: p < 0.003).345

Mobilization versus another type/method of the same CAM. No relevant studies were identified.

Mobilization versus other treatments. In two trials, mobilization (traditional bone setting technique) was compared with physiotherapy (massage, therapeutic stretching, trunk stabilization exercise, and exercise therapy) in terms of pain intensity (VAS), disability (Oswestry), back mobility (lateral bending), quality of life (HRQoL-15D questionnaire), and global assessment (scores from -1 to +10).341,343 In one of these trials,343 scores for 1 month post-treatment global assessment and quality of life were better in the mobilization compared to physiotherapy group.

Based on the results from two meta-analyses (Figures 32-33), subjects with chronic nonspecific LBP in the mobilization groups had significantly reduced immediate post-treatment pain intensity (pooled mean difference in VAS score: -0.50, 95 percent CI: -0.72, -0.28)341,343 or disability (pooled mean difference in Oswestry score: -4.93, 95 percent CI: -5.91, -3.96)341,343 compared to those in the physiotherapy groups. According to a meta-analysis of the same trials (Figure 34),341,343 the mean difference in finger to floor distance (in cm) between the mobilization and placebo groups was not statistically significant (pooled mean difference: -0.89, 95 percent CI: -1.89, 0.12)

Figure 32 Pain intensity (VAS score) – Immediate post-treatment

Figure 32 depicts Pain Intensity (VAS score) - Immediate post-treatment. On the left is a chart with three headings--Study Name, Mobilization (with subheads N and Mean (SD)), and Physiotherapy (with subheads N and Mean (SD)). On the right is another head, Difference in means and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -2, -1, 0, 1, 2. A vertical line runs up from 1 with bullets on bars and blobs representing the numbers in the studies. On the upper left of that chart are the words Favors Mobilization with an arrow pointing left, and on the upper right of the chart are the words Favors Physiotherapy with an arrow pointing right. The results, left to right, are: Ritvanen et al. 2007--33--2.3 (0.5)--28--2.8--(0.4)-- -0.50 (-0.73, -0.27); Zaproudina et al. 2009--57--2.18 (2.5)--60--2.68 (2.0)-- -0.50 (-1.31, 0.31); Pooled--90--blank--88--blank-- -0.50 (-0.72, -0.28). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 0.0, df = 1 (P = 1.00); I 2(superscript) = 0.0%.

Figure 33 Disability (Oswestry score) – Immediate post-treatment

Figure 33 depicts Disability (Oswestry score) - Immediate post-treatment. On the left is a chart with three headings--Study Name, Mobilization (with subheads N and Mean (SD)), and Physiotherapy (with subheads N and Mean (SD)). On the right is another head, Difference in means and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -10, -5, 0, 5, 10. A vertical line runs up from 1 with bullets on bars and blobs representing the numbers in the studies. On the upper left of that chart are the words Favors Mobilization with an arrow pointing left, and on the upper right of the chart are the words Favors Physiotherapy with an arrow pointing right. The results, left to right, are: Ritvanen et al. 2007--33--12.0 (2.))--28--17.0 (2.0)-- -5.00 (-6.01, -3.99); Zaproudina et al. 2009--57--12.3 (11)--60--16.3 (9.9)-- -4.00 (-7.79, -0.21); Pooled--90--blank--88--blank-- -4.93 (-5.91, -3.96). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 0.24, df = 1(P = 0.61); I 2(superscript) = 0.0%.

Figure 34 Finger to floor distance (in cm) – Immediate post-treatment

Figure 34 depicts Finger to floor distance (in cm) - Immediate post-treatment. On the left is a chart with three headings--Study Name, Mobilization (with subheads N and Mean (SD)), and Physiotherapy (with subheads N and Mean (SD)). On the right is another head, Difference in means and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -10, -5, 0, 5, 10. A vertical line runs up from 1 with bullets on bars and blobs representing the numbers in the studies. On the upper left of that chart are the words Favors Mobilization with an arrow pointing left, and on the upper right of the chart are the words Favors Physiotherapy with an arrow pointing right. The results, left to right, are: Ritvanen et al. 2007--33--5.4 (2.2)--28--6.3 (1.9)-- -0.90 (-1.94, 0.14); Zaproudina et al. 2009--57--3.1 (11.6)--60--3.8 (10.9)-- -0.70 (-4.41, 3.01); Pooled--90--blank--88--blank-- -0.89 (-1.89, 0.12). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 0.01, df = 1(P = 0.61); I 2(superscript) = 0.0%.

In one trial,344 there was no difference between subjects in the mobilization versus physiotherapy or exercise (light back movements) groups with respect to immediate and intermediate-term post-treatment pain intensity (VAS), ROM (modified Schober’s test; extension in degrees), and straight leg raising. In this study mobilization was performed by folk-healers practitioners who had no formal medical education.

Mobilization versus medication. No relevant studies were identified.

Mobilization + other treatments versus the same other treatments. No relevant studies were identified.

Mobilization versus manipulation. In one trial,279 short-term post-treatment effects of mobilization and manipulation on pain were compared. The post-treatment pain pressure threshold was similar in the manipulation and mobilization groups.

Mobilization versus massage In one trial,347 short-term post-treatment effects of mobilization and massage on pain were compared. The post-treatment pain intensity (VAS) was slightly but significantly greater in the mobilization group compared to the massage group (3.36 ± 0.25 versus 2.48 ± 0.25, p = 0.017).

Population with mixed duration of pain. Six trials were included in this sub-section.336-338,342,348,350 All of these trials enrolled subjects with nonspecific LBP in whom the effect of mobilization was compared to that of ‘no treatment’,337 placebo,348 exercise,342,350 or physiotherapy.342 In two trials,336,338 two delivery modes of mobilization were compared (therapist-selected levels versus randomly selected levels).

Subjects with specific pain.

Mobilization versus placebo. No relevant studies were identified.

Mobilization versus no treatment. No relevant studies were identified.

Mobilization versus another type/method of the same CAM. No relevant studies were identified.

Mobilization versus other treatments. No relevant studies were identified.

Mobilization versus medication. No relevant studies were identified.

Mobilization + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Mobilization versus placebo. In one trial,348 mobilization did not significantly differ from placebo (consisted of patients lying in a comfortable position with no manual intervention applied) in reducing immediate or short-term post-treatment pain intensity (VAS) or spinal ROM (flexion, extension, finger-to-floor). There was a small but a statistically significant difference in favor of mobilization (versus placebo) for improving spinal ROM (true flexion: 49.2° ± 16.4 versus 45.3 ° ± 14.1, p = 0.005; total flexion: 76.7 ° ± 22.4 versus 69.7 ° ± 21.5, p = 0.005) immediately after the treatment. The intervention was provided by experience physiotherapist trained for mobilization for movement techniques.

Mobilization versus no treatment. In one trial,337 mobilization did not significantly differ from ‘no treatment’ in reducing immediate or short-term post-treatment pain intensity (VAS) or spinal ROM (flexion, extension, finger-to-floor).

Mobilization (type1) versus mobilization (type2). In one of the two trials,336,338 comparing therapist-selected levels to randomly selected levels of mobilization, current pain intensity was significantly reduced in the therapist-selected group (1.34, 95 percent CI: 1.02, 1.66) compared to the random group (0.88, 95 percent CI: 0.52, 1.24).338 The reduction in pain (NRS-11) was greater for subjects whose most painful movement was flexion (as opposed to extension, lateral flexion). The post-treatment spinal ROM (fingertip-to-floor, flexion, extension, lateral flexion, worst movement) or global perceived effect did not differ between the groups.338 In contrast, results from the other trial,336 indicated no significant difference between the two types of mobilization in terms of immediate pain reduction (NRS-11: 1.3 ± 1.4 versus 1.2 ± 1.7, p > 0.05). Significant interaction effects were found for the most painful movement direction for the left (p = 0.006) and right lateral flexion (p = 0.02).

A series of meta-analyses based on the above-mentioned trials (Figures 35-41)336,338 did not show any significant differences between the two modalities of mobilization for mean improvement in pain intensity (pooled mean reduction in VAS score: 0.29, 95 percent CI: -0.06, 0.64), global perceived scale (0.20, 95 percent CI: -0.23, 0.62), extension (pooled mean change in degrees: 0.01, 95 percent CI: -0.83, 0.85), flexion (pooled mean change in degrees: 0.90, 95 percent CI: 0.16, 1.96), and finger to floor distance (pooled mean change in degrees: 0.88, 95 percent CI: -0.12, 1.88). Similarly, the pooled estimates for differences between mean changes of the two groups for right lateral flexion (0.14, 95 percent CI: -0.51, 0.79) and left lateral flexion (mean degrees: 0.31, 95 percent CI: -0.35, 0.96) were not statistically significant.

Figure 35 Pain intensity (VAS score) – Immediate post-treatment

Figure 35 depicts Pain intensity (VAS score) - Immediate post-treatment. On the left is a chart with three headings--Study Name, Therapist (with subheads N and Mean (SD)), and Random (with subheads N and Mean (SD)). On the right is another head, Difference in mean change from baseline and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -5, -2.5, 0 2.5, 5. A vertical line runs up from 1 with bullets on bars and blobs representing the numbers in the studies. On the upper left of that chart are the words Favors Random with an arrow pointing left, and on the upper right of the chart are the words Favors Therapist with an arrow pointing right. The results, left to right, are: Chiradejnant et al. 2003--70--1.3 (1.4)--70--1.2 (1.7)--0.10 (-0.42, 0.62); Chiradejnant et al. 2002--60--1.34 (1.3)--60--0.88 (1.4)--0.46 (-0.02, 0.94); Pooled--130--blank--130--blank--0.29 (-0.06, 0.64). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 0.9, df = 1(P = 0.31); I 2(superscript) = 0.0%.

Figure 36 Global perceived scale – Immediate post-treatment

Figure 36 depicts Global perceived scale - Immediate post-treatment. On the left is a chart with three headings--Study Name, Therapist (with subheads N and Mean (SD)), and Random (with subheads N and Mean (SD)). On the right is another head, Difference in mean change from baseline and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -5, -2.5, 0 2.5, 5. A vertical line runs up from 1 with bullets on bars and blobs representing the numbers in the studies. On the upper left of that chart are the words Favors Random with an arrow pointing left, and on the upper right of the chart are the words Favors Therapist with an arrow pointing right. The results, left to right, are: Chiradejnant et al. 2003--70--1.4 (1.8)--70--1.2 (1.9)--0.20 (-0.41, 0.81); Chiradejnant et al. 2002--60--1.28 (1.4)--60--1.09 (1.9)--0.19 (-0.41, 0.79); Pooled--130--blank--130--blank--0.20 (-0.23, 0.62). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 0.0, df = 1(P = 0.98); I 2(superscript) = 0.0%.

Figure 37 Range of mobility (lumbar extension) – Immediate post-treatment

Figure 37 depicts Range of Mobility (lumbar extension) - Immediate post-treatment. On the left is a chart with three headings--Study Name, Therapist (with subheads N and Mean (SD)), and Random (with subheads N and Mean (SD)). On the right is another head, Difference in mean change from baseline and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -5, -2.5, 0 2.5, 5. A vertical line runs up from 1 with bullets on bars and blobs representing the numbers in the studies. On the upper left of that chart are the words Favors Random with an arrow pointing left, and on the upper right of the chart are the words Favors Therapist with an arrow pointing right. The results, left to right, are: Chiradejnant et al. 2003--70--2.2 (2.9)--70--2.6 (2.8)--- -0.40 (-1.34, 0.54); Chiradejnant et al. 2002--60--2.48 (2.8)--60--2.02 (2.9)--0.46 (0.55, 1.47); Pooled--130--blank--130--blank--0.01 (-0.83, 0.85). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 1.5, df = 1(P = 0.2); I 2(superscript) = 32.6%.

Figure 38 Range of mobility (lumbar flexion) – Immediate post-treatment

Figure 38 depicts Range of Mobility (lumbar flexion) - Immediate post-treatment. On the left is a chart with three headings--Study Name, Therapist (with subheads N and Mean (SD)), and Random (with subheads N and Mean (SD)). On the right is another head, Difference in mean change from baseline and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -5, -2.5, 0 2.5, 5. A vertical line runs up from 1 with bullets on bars and blobs representing the numbers in the studies. On the upper left of that chart are the words Favors Random with an arrow pointing left, and on the upper right of the chart are the words Favors Therapist with an arrow pointing right. The results, left to right, are: Chiradejnant et al. 2003--70--3.5 (3.8)--70--1.9 (6.5)-- 1.60 (-0.16, 3.36); Chiradejnant et al. 2002--60-1.8 (4.)--60--1.3 (3.4)--0.50 (-0.83, 1.83); Pooled--130--blank--130--blank--0.90 (0.16, 1.96). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 0.9, df = 1(P = 0.32); I 2(superscript) = 0.0%.

Figure 39 Finger to floor distance (in cm) – Immediate post-treatment

Figure 39 depicts Finger to floor distance (in cm) - Immediate post-treatment. On the left is a chart with three headings--Study Name, Therapist (with subheads N and Mean (SD)), and Random (with subheads N and Mean (SD)). On the right is another head, Difference in mean change from baseline and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -5, -2.5, 0 2.5, 5. A vertical line runs up from 1 with bullets on bars and blobs representing the numbers in the studies. On the upper left of that chart are the words Favors Random with an arrow pointing left, and on the upper right of the chart are the words Favors Therapist with an arrow pointing right. The results, left to right, are: Chiradejnant et al. 2003--70--2 (2.6)--70--0.5 (5.6)--- 1.50 (0.05, 2.95); Chiradejnant et al. 2002--60--1.5 (3.8)-60--1.04 (2.5)--0.46 (-0.68, 1.60); Pooled--130--blank--130--blank--0.88 (-0.12, 1.88). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 1.2, df = 1(P = 0.26); I 2(superscript) = 18/2%.

Figure 40 Range of mobility (right lateral flexion; in degrees) – Immediate post-treatment

Figure 40 depicts Range of Mobility (right lateral flexion; in degrees) - Immediate post-treatment. On the left is a chart with three headings--Study Name, Therapist (with subheads N and Mean (SD)), and Random (with subheads N and Mean (SD)). On the right is another head, Difference in mean change from baseline and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -5, -2.5, 0 2.5, 5. A vertical line runs up from 1 with bullets on bars and blobs representing the numbers in the studies. On the upper left of that chart are the words Favors Random with an arrow pointing left, and on the upper right of the chart are the words Favors Therapist with an arrow pointing right. The results, left to right, are: Chiradejnant et al. 2003--70--2.0 (2.5)--70--1.9 (2.7)-- 0.10 (-0.76, 0.96); Chiradejnant et al. 2002--60--2.57 (2.)--60--2.37 (2.6)--0.20 (-0.79, 1.19); Pooled--130--blank--130--blank--0.14 (-0.51, 0.79). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 0.02, df = 1(P = 0.88); I 2(superscript) = 0.0%.

Figure 41 Range of mobility (left lateral flexion; in degrees) – Immediate post-treatment

Figure 41 depicts Range of Mobility (left lateral flexion, in degrees) - Immediate post-treatment. On the left is a chart with three headings--Study Name, Therapist (with subheads N and Mean (SD)), and Random (with subheads N and Mean (SD)). On the right is another head, Difference in mean change from baseline and 95% CI, with a chart with a horizontal line at the bottom with the numbers, left to right, -5, -2.5, 0 2.5, 5. A vertical line runs up from 1 with bullets on bars and blobs representing the numbers in the studies. On the upper left of that chart are the words Favors Random with an arrow pointing left, and on the upper right of the chart are the words Favors Therapist with an arrow pointing right. The results, left to right, are: Chiradejnant et al. 2003--70--2.2 (2.6)--70--2.2 (2.6)---0.00 (-0.86, 0.86); Chiradejnant et al. 2002--60--2.75 (2.9)--60--2.08 (2.4)--0.67 (-0.27, 1.61); Pooled--130--blank--130--blank--0.31 (-0.35, 0.96). On the bottom left of the figure are the words Heterogeneity: Chi 2(superscript) = 1.0, df = 1(P = 0.30); I 2(superscript) = 5.6%.

Mobilization versus other treatments. Results from two trials comparing mobilization to a press up exercise indicated either no significant difference between the two in reducing pain (VAS) and lumbar ROM (total lumbar extension) immediately after the end of a single treatment350 or a slight numerical difference in favor of mobilization (bone-setting) (versus exercise) in reducing disability (Oswestry) at intermediate-term after the end of 6 weeks treatment (manual, thermal, and electrotherapies according to the Finnish routine) within-group reductions: 5.9 percent, p = 0.009 versus 6.2 percent, p = 0.02, respectively).342 In the second trial,342 there was no difference between bone-setting and physiotherapy in terms of reduction of the Oswestry disability score (within-group reductions: 4.7 versus 4.0). In this trial, reduction in number of sick leaves was not statistically or clinically significant between the three groups during one year post intervention. The average number of visits to health centers for back pain decreased in all groups, with significant changes only in physiotherapy (mean change from year before therapy = 0.5 compared with 0.1 in bone setting, and -0.1 in exercise group, p < 0.1).342

Mobilization versus medication. No relevant studies were identified.

Mobilization + other treatments versus the same other treatments. No relevant studies were identified.

Population with unknown duration of pain. One trial was included in this section. This trail included subjects with lumbar intervertebral disc protrusion-induced back-leg pain.340

Subjects with specific pain.

Mobilization versus placebo. No relevant studies were identified.

Mobilization versus no treatment. No relevant studies were identified.

Mobilization versus massage. In one trial of subjects with LBP due to disc protrusion, there was no statistically significant difference in post-treatment pain intensity on VAS (5.59 ± 0.80 versus 4.71 ± 0.52, p > 0.05) between the groups of mobilization (oblique-pulling method) and massage (kneading method of tender points).340

Mobilization versus other treatments. No relevant studies were identified.

Mobilization versus medication. No relevant studies were identified.

Mobilization + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Mobilization versus placebo. No relevant studies were identified.

Mobilization versus no treatment. No relevant studies were identified.

Mobilization versus another type/method of the same CAM. No relevant studies were identified.

Mobilization versus other treatments. No relevant studies were identified.

Mobilization versus medication. No relevant studies were identified.

Mobilization + other treatments versus the same other treatments. No relevant studies were identified.

#### 10 Mobilization for Treatment of Neck Pain

This section included 11 trials. Note that two trials were reported in multiple publications (Table 3). Results from four trials comparing mobilization to manipulation,65,308-310 are presented in the Spinal Manipulation section. Results from one trial are presented in Acupuncture section.265 Results of cost effectiveness for one trial62-64 are reported in the respective section.

Population/trial characteristics. The trials were conducted in Finland (two)352,353, Belgium (one)354, Canada (two)309,355, Spain (one)310, Germany (one)308, Sweden (one)356, Thailand (one)357, United States (one)65, and the Netherlands (one).62

In total, 1,504 patients were included in these trials. All studies recruited adults aged 18 years or older. In four studies, the majority were women.65,310,352,354 The proportion of men and women was similar in four studies,308,353,355,357 and differed in one study,358 and were not reported for two studies.309,356 Table 18 presents the control interventions in the included studies.

Table 18 Spinal mobilization for treatment of neck pain- Control interventions

Type of control group | Cause of Pain | N studies | Detail of Control intervention
1 – Inactive treatments
Placebo/sham | Non Specific | 3 | Manual contact without any movement of cervical spine or tension in the region,308,355,356
Placebo/sham | Specific | 0 | NA
No-treatment/ waiting list | Non Specific | 1 | No physical contact355
No-treatment/ waiting list | Specific | 0 | NA
2 – Active treatments
Education | Non Specific | 0 | NA
Education | Specific (whiplash) | 1 | Information and advise on staying active,359
Physiotherapy | Nonspecific | 1 | Massage, therapeutic stretching, and exercise therapy,353
Physiotherapy | Specific | 0 | NA
Cervical collar | Nonspecific | 0 | NA
Cervical collar | Specific (whiplash) | 1 | Semi-rigid neck collar,359
Physical modalities | Nonspecific | 0 | NA
Physical modalities | Specific | 1 | Ultrasound,354
Manual therapy | Nonspecific | 4 | Manipulation,65,308-310massage,353
Manual therapy | Specific | 0 | NA
Other methods of mobilization | Nonspecific | 1 | Randomly selected (vs. therapist selected) mobilization357
Other methods of mobilization | Specific | 1 | Antero-posterior unilateral pressure,320cervical oscillatory rotation,320transverse oscillatory pressure320

NA= not applicable

In five trials, single session of treatment was applied.309,310,354,355,357 The duration of treatment in the remaining six trials was up to 8 weeks.62,65,308,352,353,356

Risk of bias. The risk-of-bias graph for the trials included in this sub-section is presented in Figure 42. All trials were randomized. The adequate method of randomization and treatment allocation concealment was reported for 44.0 percent and 56.0 percent of the trials, respectively. About 67.0 percent of the trials reported that distribution of the subjects’ baseline characteristics across the treatment arms was similar. In 78.0 percent of the trials, study participants were not blinded to the treatment. Up to 56.0 percent of the trials reported acceptable drop-out rate. Results based on intention-to-treat analysis were explicitly reported for 22.0 percent of the trials. The data for selected items of the risk of bias tool across the CAM interventions (acupuncture; spinal manipulation; spinal mobilization; combination of manipulation and mobilization; and massage therapy) is displayed in table 7.2 of Appendix G.

Figure 42 Risk of bias scores (%)

Figure 42 depicts the Risk of bias scores percents as a bar graph. On the left hand side are listed, vertically, Q1 through Q13. A horizontal solid black line represents Yes, a gray line, No, and a dotted line, Unclear. At the bottom, left to right, are the percentages 0%, 20%, 40%, 60% 80%, and 100%. Q1 is Yes 0 to about 40%. No about 40% to about 55% Unclear about 55% to 100%. Q2 is Yes 0 to about 55%, No about 55% to 65%, Unclear, about 65% to 100%. Q3 is Yes 0% to about 65%, No about 65% to about 70%, and Unclear about 70% to 100%. Q4 is Yes 0% to 10%, No 10% to about 90%, and Unclear about 90% to 100%. Q5 is Yes to about 20%, No 20% to 100%. Q6 is Yes 0% to about 60%, Unclear about 60% to 100%. Q7 is Yes 0% to about 10%, Unclear about 10% to 100%. Q8 is Yes 0% to about 45%, Unclear about 45% to 100%. Q9 is Yes 0 to about 55%, No 55% to about 65%, Unclear about 65% to 100%. Q10 is Yes 0 to about 100%. Q11 is Yes 0% to about 22%, No about 22% to about 45%, and Unclear about 45% to 100%. Q12 is Yes 0% to about 70%, No about 70% to 100%. Q13 is No 0 to about 10%, and Unclear about 10% to 100%.

Efficacy results. A summary of the key results is presented in Table 19. For more detail of trials please see evidence tables. (Appendix C, table 2.18 – table 2.19)

Table 19 Key results – Mobilization therapy for neck pain

CAM therapy | Duration of pain | Cause of pain | Outcome | Risk-of-bias | Precision of the pooled estimate | Consistency | Directness | Finding | GRADE^ψ^
Mob vs. No Tx | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Mob vs. No Tx | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Mob vs. No Tx | Chronic | S | - | - | - | - | - | - | Insufficient
Mob vs. No Tx | Chronic | NS | VAS: B355 | M | - | NA | Direct | > SS | Low
Mob vs. No Tx | Chronic | NS | PPT: B355 | M | - | NA | Direct | > SS | Low
Mob vs. No Tx | Mixed | S | - | - | - | - | - | - | Insufficient
Mob vs. No Tx | Mixed | NS | VAS: B352 | H | - | NA | Direct | > SS | Low
Mob vs. No Tx | Mixed | NS | Pain medications taken (# of pills annually): B, C352 | H | - | NA | Indirect | = S-NS | Low
Mob vs. No Tx | Mixed | NS | # of sick leave days: B, C, D352 | H | - | NA | Indirect | = S-NS | Low
Mob vs. No Tx | Unknown | S | - | - | - | - | - | - | Insufficient
Mob vs. No Tx | Unknown | NS | - | - | - | - | - | - | Insufficient
Mob vs. PL | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Mob vs. PL | Acute/subacute | NS | VAS: B308 | M | - | NA | Direct | > SS | Low
Mob vs. PL | Chronic | S | - | - | - | NA | - | - | Insufficient
Mob vs. PL | Chronic | NS | VAS: B355 | M | - | NA | Direct | = S-NS | Low
Mob vs. PL | Chronic | NS | PPT: B355 | M | - | NA | Direct | > SS | Low
Mob vs. PL | Mixed | S | - | - | - | - | - | - | -
Mob vs. PL | Mixed | NS | - | - | - | - | - | - | Insufficient
Mob vs. PL | Unknown | S | - | - | - | - | - | - | Insufficient
Mob vs. PL | Unknown | NS | - | - | - | - | - | - | Insufficient
Mob vs. Ma | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Mob vs. Ma | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Mob vs. Ma | Chronic | S | - | - | - | - | - | - | Insufficient
Mob vs. Ma | Chronic | NS | VAS: D353 | M | - | NA | Direct | > SS | Low
Mob vs. Ma | Chronic | NS | NDI: D353 | M | - | NA | Direct | > SS | Low
Mob vs. Ma | Chronic | NS | # of sick leave days: D353 | M | - | NA | Indirect | > SS | Low
Mob vs. Ma | Chronic | NS | Global assessment (score: -1, +10): D353 | M | - | NA | Indirect | > SS | Low
Mob vs. Ma | Chronic | NS | ROM (rotation, frons-knee distance): D353 | M | - | NA | Indirect | = S-NS | Low
Mob vs. Ma | Mixed | S | - | - | - | - | - | - | Insufficient
Mob vs. Ma | Mixed | NS | - | - | - | - | - | - | Insufficient
Mob vs. Ma | Unknown | S | - | - | - | - | - | - | Insufficient
Mob vs. Ma | Unknown | NS | - | - | - | - | - | - | Insufficient
Mob vs. PT | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Mob vs. PT | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Mob vs. PT | Chronic | S | - | - | - | - | - | - | Insufficient
Mob vs. PT | Chronic | NS | VAS: D353 | M | - | NA | Direct | > SS | Low
Mob vs. PT | Chronic | NS | NDI: D353 | M | - | NA | Direct | > SS | Low
Mob vs. PT | Chronic | NS | # of sick leave days: D353 | M | - | NA | Indirect | > SS | Low
Mob vs. PT | Chronic | NS | % pts using analgesics: D353 | M | - | NA | Indirect | > SS | Low
Mob vs. PT | Mixed | S | - | - | - | - | - | - | Insufficient
Mob vs. PT | Mixed | NS | VAS:D62 | H | - | NA | Direct | > SS | Low
Mob vs. PT | Mixed | NS | NDI: D62 | H | - | NA | Direct | = S-NS | Low
Mob vs. PT | Unknown | S | - | - | - | - | - | - | Insufficient
Mob vs. PT | Unknown | NS | - | - | - | - | - | - | Insufficient
Mob vs. ST | Acute/subacute | S | - | - | - | - | - | - | -
Mob vs. ST | Acute/subacute | NS | - | - | - | - | - | - | -
Mob vs. ST | Chronic | S | - | - | - | - | - | - | -
Mob vs. ST | Chronic | NS | - | - | - | - | - | - | -
Mob vs. ST | Mixed | S | - | - | - | - | - | - | -
Mob vs. ST | Mixed | NS | VAS: D62 | H | - | NA | Direct | = S-NS | Low
Mob vs. ST | Mixed | NS | NDI: D62 | H | - | NA | Direct | = S-NS | Low
Mob vs. ST | Unknown | S | - | - | - | - | - | - | -
Mob vs. ST | Unknown | NS | - | - | - | - | - | - | -

S=specific; NS=nonspecific; SS=statistically significant; S-NS=statistically nonsignificant; Man=manipulation; Acu=acupuncture; Ma=massage; Mob=mobilization; PL=placebo; Tx=treatment. Med=medication(s); Int=intervention; PT=physiotherapy; ST=standard therapy; E-acu=electro-acupuncture; MR=muscle relaxation; TENS= transcutaneous electrical nerve stimulation; Ex=exercise; TrP=trigger point; VAS=visual analog scale; RMDQ=Roland Morris Disability scale; NHP=Nottingham Health Profile; PPT= pressure pain threshold; HFAQ=Hanover functional ability questionnaire; MPQ=McGill pain questionnaire; ext=extension; flx=flexion; rot=rotation; PDI=pain disability index; min=minute(s); hr(s)=hour(s); L=low; M=medium; H=high; pt(s)=patient(s); SF=short-form; NPQ=neck pain questionnaire; GWBS=global well-being scale; SLR=straight leg raising; GPE= Global perceived effect; NSAIDS=nonsteroidal antiinflammatory drugs; FTF=finger-to-floor; SF-PQ=short form pain questionnaire; PRI=pain rating index; PPI=present pain intensity; NA=not applicable

^ψ^ Grade (High, moderate, low, and insufficient)

B = immediate post-treatment

C = short-term post-treatment

D = intermediate-term post-treatment

E = long-term post-treatment

H = high

L = low

M = medium

- No evidence

= Similar beneficial effect

> Favors treatment A over treatment B

< Favors treatment B over treatment A

><, =>, <= Inconsistent beneficial effect

Population with acute/subacute duration of pain. One trial,308 was included in this section. This trial enrolled patients with nonspecific pain. Additional results from this trial are also reported in the Spinal Manipulation, Acute Neck Pain sub-section.

Subjects with specific pain.

Mobilization versus placebo. No relevant studies were identified.

Mobilization versus no treatment. No relevant studies were identified.

Mobilization versus another type/method of the same CAM. No relevant studies were identified.

Mobilization versus other treatments. No relevant studies were identified.

Mobilization versus medication. No relevant studies were identified.

Mobilization + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Mobilization versus placebo. In one trial,308 patients in mobilization group had significantly (p < 0.01) lower intensity of pain compared to placebo (hand placement without any pressure or tension).

Mobilization versus no treatment. No relevant studies were identified.

Mobilization versus another type/method of the same CAM. No relevant studies were identified.

Mobilization versus other treatments. No relevant studies were identified.

Mobilization versus medication. No relevant studies were identified.

Mobilization + other treatments versus the same other treatments. No relevant studies were identified.

Population with chronic duration of pain. There were two trials included in this sub-section, one studied subjects with nonspecific chronic neck pain,355 and the other - subjects with specific chronic neck pain.358

Subjects with specific pain.

Mobilization versus placebo. No relevant studies were identified.

Mobilization versus no treatment. No relevant studies were identified.

Mobilization versus another type/method of the same CAM. No relevant studies were identified.

Mobilization versus other treatments. No relevant studies were identified.

Mobilization versus medication. No relevant studies were identified.

Mobilization + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Mobilization versus placebo. In one trial,355 post-treatment mean VAS scores were not significantly different between mobilization and placebo (hand placement without movement of vertebral segment) groups (p = 0.09). However, the mobilization group had a significantly greater PPT mean score compared to the placebo group.

Mobilization versus no treatment. In one trial,355 post-treatment mean PPT and VAS scores in the mobilization group were significantly greater compared to no treatment group (p < 0.001 and p = 0.04, respectively).

Mobilization versus another type/method of the same CAM. No relevant studies were identified

Mobilization versus other treatments (including CAM). In one trial,353 subjects who received bone setting experienced significantly greater improvements in pain intensity (PPT, VAS) and disability level (NDI) compared to patients who received physiotherapy (massage, therapeutic stretching, and exercise therapy) or traditional massage. Moreover, patients in the bone-setting group during 1 year of followup had a lower number of sick leave days (0.61 per person) compared to those in the physiotherapy (2.6 per person) or the traditional massage group (3.9 per person). Similarly, the bone-setting group had a greater percent decrease in the use of analgesics compared to physiotherapy and traditional massage groups (65.7 percent, 50.0 percent, and 56.2 percent, respectively).

Mobilization versus medication. No relevant studies were identified.

Mobilization + other treatments versus the same other treatments. No relevant studies were identified.

Population with mixed duration of pain. There were eight trials included in this section.62,65,309,310,352,354,356,357 Only one trial included patients with pain due to specific cause - neurogenic disorder.354 In these trials clinical benefits/harms of mobilization were compared to those of no treatment,352 manipulation,65,309,310 mobilization,357 placebo,354, continued GP care,62 physiotherapy,62 or analgesic medication.356

Results from three trials where mobilization is compared to manipulation,65,309,310 are also presented in the Spinal Manipulation, Mixed Duration Neck Pain sub-sections.

Subjects with specific pain.

Mobilization versus placebo. No relevant studies were identified.

Mobilization versus no treatment. No relevant studies were identified.

Mobilization versus another type/method of the same CAM. No relevant studies were identified.

Mobilization versus other treatments. In a small trial of 20 patients diagnosed with neurogenic cervicobrachial pain,354 the efficacy of mobilization performed by physical therapist was compared to pulsed ultrasound applied over the painful area. The application of mobilization technique was associated with statistically significant immediate post-treatment improvement compared to baseline in pain intensity on VAS (from 7.3 ± 1.8 to 5.8 ± 2.1, p = 0.005) and cervical ROM (from 137.3 ± 15.4 to 156.7 ± 10.7, p = 0.0005). In contrast, in control group, the corresponding within-group changes in VAS (from 7.7 ± 1.9 to 7.4 ± 1.8, p = 0.16) and ROM (from 130.2 ± 14.7 to 130.7 ± 16.0, p = 0.78) were not significant. Statistical test results for the inter-group comparisons (mobilization versus placebo) were not provided.354

Mobilization versus medication. No relevant studies were identified.

Mobilization + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Mobilization versus placebo. No relevant studies were identified.

Mobilization versus no treatment. In one study,352 the use of bone-setting resulted in a significantly greater proportion of improved subjects (> 50 percent improvement in VAS) compared to control group (neither offered nor denied treatment) after 5 weeks (p = 0.04) and 6 months ( p = 0.002) of treatment. This difference was not statistically significant after one year (p = 0.2). In this trial slight self-rated improvement compared with baseline was reported after 5 weeks by 20/21 subjects in the massage group versus 3/17 subjects in the control group (p < 0.001). These rates were 15/20 versus 6/18 (p = 0.01) after 5 weeks, and 16/20 versus 5/18 (p = 0.002) after one year. There were no statistically significant differences between bone-setting and the no treatment group in the annual number of pain medications taken (63 ± 146 versus 188 ± 332, p = 0.1) and the number of sick leave days (4.5 ± 20.0 versus 16.9 ± 53, p = not reported).352

Mobilization (type 1) versus mobilization (type 2). One trial,357 comparing an immediate post-treatment effect of randomly chosen mobilization versus preferred mobilization, showed similar degree of global perceived effect (an ordinal 7-point scale; ranging from 1 = completely recovered to worse than ever = 7) and pain intensity (VAS) between the two groups. The same trial indicated the preferred mobilization group being superior to randomly chosen mobilization group with respect to cervical flexion ROM (p = 0.024).

Mobilization versus other treatments. In one trial,62 spinal mobilization led to statistically significant improvement in pain intensity (VAS) compared to GP care which consisted of counseling and advice on staying active, role of psychosocial factors, self-care such as heat application, home exercises, and ergonomic advice (mean difference 0.9, 95 percent CI: 0.1, 1.5) but not to physiotherapy including specific exercises (mean difference 0.3, 95 percent CI: -0.6, 1.2) in short term followup. At the same followup, there was no significant difference for disability (NDI) between the treatment groups. At 52 weeks, spinal manipulation faired statistically significantly better than physiotherapy (mean difference 1.0, 95 percent CI: 0.1, 1.9) in improving pain intensity (VAS), but not compared to GP care (mean difference 0.5, 95 percent CI: -0.4, 1.3).

Mobilization versus medication. No relevant studies were identified.

Mobilization + other treatments versus the same other treatments. In one trial,356 short-term post-treatment analgesic effect of mobilization and medication (Premaspin 0.5 g daily) was significantly greater compared to the same medication alone (pain free subjects: 48 percent versus 12 percent, p < 0.05).

Population with unknown duration of pain.

Subjects with specific pain.

Mobilization versus placebo. No relevant studies were identified.

Mobilization versus no treatment. No relevant studies were identified.

Mobilization (type 1) versus mobilization (type 2). In one trial,320 there was a significantly (p < 0.001) higher proportion of pain-free subjects in the anterior-posterior unilateral pressure (63.0 percent) and posterior-anterior unilateral pressure (46.0 percent) groups compared to subjects in the cervical oscillatory rotation (17.0 percent) and transverse oscillatory pressure groups (25.0 percent). This trial included patients with cervical spondylolysis.

Mobilization versus other treatments. No relevant studies were identified.

Mobilization versus medication. No relevant studies were identified.

Mobilization + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Mobilization versus placebo. No relevant studies were identified.

Mobilization versus no treatment. No relevant studies were identified.

Mobilization versus another type/method of the same CAM. No relevant studies were identified.

Mobilization versus other treatments. No relevant studies were identified.

Mobilization versus medication. No relevant studies were identified.

Mobilization + other treatments versus the same other treatments. No relevant studies were identified.

#### 11 Massage for Treatment of Low Back Pain

A total of 20 trials were included in this section. Four trials were reported in multiple publications (Table 3).

Population/trial characteristics. The trials were conducted in Belgium (one),360 Canada (one),361 China (two),340,362 Germany (one),41 Hungary (one),363 Taiwan (two),364,365 Hong Kong (one),366 Thailand (two),347,367 United Kingdom (three),90,368,369 and United States (six).29,101,295,370-372

The proportions of women and men were similar for 13 studies (40.0 percent-60.0 percent).29,41,295,340,360-363,365,369-372 In five studies, there were more women than men,90,347,364,366,367 and in one – more men.101 The proportions of men and women could not be ascertained for one trial.368

The study participants were adults aged 18 or older. Information regarding ethnicity was reported for only three trials.29,370,372 For one Chinese study, the participants’ ethnicity was assumed to be Asian.362 The majority of subjects (> 65.0 percent) in two studies were Caucasians.29,372 The remaining studies did not report any data on ethnicity.

In total 2,953 subjects with low back pain (of specific and nonspecific cause) were included in these trials and 884 of them were randomized to massage treatment. Table 20 presents the control interventions in the included studies.

Table 20 Massage for treatment of low back pain- Control interventions

Type of control group | Cause of Pain | N studies | Detail of Control intervention
1 – Inactive treatments
Placebo/sham | Non Specific | 3 | Foot massage (avoiding points representative of the vertebrae of the spine and surrounding musculature),368, minimal but continuous suction delivered by device,360sham laser361
Placebo/sham | Specific | 0 | NA
No-treatment/waiting list | Non Specific | 2 | Routinely examined without therapy,360,363,366
No-treatment/waiting list | Specific | 0 | NA
2 – Active treatments
Exercise/physical activity | Non Specific | 3 | Specific (1^st^ group), and nonspecific (2^nd^ group) exercise in addition to sham massage,371Alexander lesson techniques (multiple groups with various doses)90training for home program,373
Exercise/physical activity | Specific | 0 | NA
Usual care | Non Specific | 3 | prescription by physician, and behavioral counseling with practice nurse,90continued care by general practitioner369self care,29
Usual care | Specific | 0 | NA
Physiotherapy | Nonspecific | 3 | pelvic manual traction, spinal manipulation, thermotherapy, infrared light therapy, electrical stimulation, and exercise,364,365massage + exercise + postural education361
Physiotherapy | Specific | 0 | NA
Relaxation | Nonspecific | 3 | Progressive muscle relaxation techniques369,370,372
Relaxation | Specific | 0 | NA
Other | Nonspecific | 2 | Lumbar corset,101balenotherapy (mineral hydrotherapy) in two groups: with and without traction,363traction,362
Other | Specific | 0 | NA
Physical modalities | Nonspecific | 2 | TENS,101,374
Physical modalities | Specific | 0 | NA
Manual therapy | Nonspecific | 4 | Manipulation,101,292,295, mobilization,347
Manual therapy | Specific | 1 | Oblique pulling (mobilization technique),340
Other methods of massage | Nonspecific | 1 | Swedish massage (light stroking or effleurage, and petrissage),367
Other methods of massage | Specific | 0 | NA
Massage in combination with another treatment (versus massage alone) | Nonspecific | 0 | NA
Massage in combination with another treatment (versus massage alone) | Specific | 3 | Individual gymnastic exercise,41exercise362electro therapy339

NA= not applicable; TENS=transcutaneous electrical nerve stimulation

Generally, trials included multi-session treatments which ranged from under 14 treatments,29,41,90,101,295,340,361,363-365,367-370,372-374 to 20 sessions339,362 in the course for the trial ranging from three to 10 weeks in total. Two studies were designed as single intervention trials.347,360

Risk of bias. The risk-of-bias graph for the trials included in this sub-section is presented in Figure 43. All trials were randomized. The adequate method of randomization and treatment allocation concealment was reported for 50.0 percent and 20.0 percent of the trials, respectively. About 90.0 percent of the trials reported that distribution of the subjects’ baseline characteristics across the treatment arms was similar. In half of the trials, study participants were not blinded to the treatment. Up to 70.0 percent of the trials reported acceptable drop-out rate. Results based on intention-to-treat analysis were explicitly reported for 50.0 percent of the trials. The data for selected items of the risk of bias tool across the CAM interventions (acupuncture; spinal manipulation; spinal mobilization; combination of manipulation and mobilization; and massage therapy) is displayed in table 7.1 of Appendix G.

Figure 43 Risk of bias scores (%)

Figure 43 depicts a Risk-of-bias graph for the trials presented as a bar graph. On the left hand side listed vertically are Q1 through Q13. A horizontal solid black line represents Yes, a gray line, No, and a dotted line, Unclear. At the bottom, left to right, are the percentages 0%, 20%, 40%, 60%, 80%, and 100%. Q1 is yes 0 to about 50%. No, about 50% to about 58%; and Unclear about 59% to 100%. Q2 is yes 0 to about 25%. No, about 26% to about 40%; and Unclear about 41% to 100%. Q3 is yes 0 to about 90%. No, about 91% to about 95%; and Unclear about 96% to 100%. Q4 is yes 0 to about 18%. No, about 19% to about 70%; and Unclear about 71% to 100%. Q5 is yes 0 to about 70%., and Unclear about 71% to 100%. Q6 is yes 0 to about 40%. No, about 41% to about 50%; and Unclear about 51% to 100%. Q7 is yes 0 to about 35% and Unclear about 36% to 100%. Q8 is yes 0 to about 60%. No, about 61% to about 68%; and Unclear about 69% to 100%. Q9 is yes 0 to about 70%. No, about 71% to about 80%; and Unclear about 81% to 100%. Q10 is yes 0 to about 95% and Unclear about 95% to 100%. Q11 is yes 0 to about 50%. No, about 51% to about 80%; and Unclear about 81% to 100%. Q12 is yes 0 to about 65%. No, about 66% to about 85%; and Unclear about 86% to 100%. Q13 is yes 0 to about 10%. No, about 11% to about 25%; and Unclear about 26% to 100%.

Efficacy results. A summary of the key results is presented in Table 21. For more detail of trials please see evidence tables. (Appendix C, table 1.35 – table 1.41)

Table 21 Key results – Massage therapy for low back pain

CAM therapy | Duration of pain | Cause of pain | Outcome | Risk-of-bias | Precision of the pooled estimate | Consistency | Directness | Finding | GRADE^ψ^
Massage vs. No Tx | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Massage vs. No Tx | Acute/subacute | NS | VAS: C360 | M | - | NA | Direct | > SS | Low
Massage vs. No Tx | Acute/subacute | NS | Oswestry: C360 | M | - | NA | Direct | > SS | Low
Massage vs. No Tx | Chronic | S | - | - | - | - | - | - | Insufficient
Massage vs. No Tx | Chronic | NS | VAS: B, D369 | M | - | NA | Direct | = S-NS | Low
Massage vs. No Tx | Chronic | NS | Oswestry: B, D369 | M | - | NA | Direct | = S-NS | Low
Massage vs. No Tx | Chronic | NS | GHP: B, D369 | M | - | NA | Direct | = S-NS | Low
Massage vs. No Tx | Chronic | NS | SF-36: B, D369 | M | - | NA | Direct | = S-NS | Low
Massage vs. No Tx | Mixed | S | - | - | - | - | - | - | Insufficient
Massage vs. No Tx | Mixed | NS | - | - | - | - | - | - | Insufficient
Massage vs. No Tx | Unknown | S | - | - | - | - | - | - | Insufficient
Massage vs. No Tx | Unknown | NS | - | - | - | - | - | - | Insufficient
Massage vs. PL | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Massage vs. PL | Acute/subacute | NS | VAS: B, C360,361 | M | - | Yes | Direct | > SS | Moderate
Massage vs. PL | Acute/subacute | NS | Oswestry: C360, | M | - | NA | Direct | > SS | Low
Massage vs. PL | Acute/subacute | NS | RMDQ: B, C361 | M | - | NA | Direct | > SS | Low
Massage vs. PL | Acute/subacute | NS | MPQ: B, C360,361 | M | - | Yes | Direct | > SS | Moderate
Massage vs. PL | Chronic | S | - | - | - | - | - | - | Insufficient
Massage vs. PL | Chronic | NS | VAS: D368 | H | - | NA | Direct | = NR | Low
Massage vs. PL | Chronic | NS | MPQ: D368 | H | - | NA | Direct | = NR | Low
Massage vs. PL | Chronic | NS | RMDQ: D368 | H | - | NA | Direct | = NR | Low
Massage vs. PL | Chronic | NS | SF-36: D368 | H | - | NA | Direct | = NR | Low
Massage vs. PL | Mixed | S | - | - | - | - | - | - | Insufficient
Massage vs. PL | Mixed | NS | - | - | - | - | - | - | Insufficient
Massage vs. PL | Unknown | S | - | - | - | - | - | - | Insufficient
Massage vs. PL | Unknown | NS | - | - | - | - | - | - | Insufficient
Massage vs. PT | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Massage vs. PT | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Massage vs. PT | Chronic | S | - | - | - | - | - | - | Insufficient
Massage vs. PT | Chronic | NS | VAS: D364 | M | - | NA | Direct | > SS | Low
Massage vs. PT | Chronic | NS | SF-PQ: B, D365 | M | - | NA | Direct | > SS | Low
Massage vs. PT | Chronic | NS | RMDQ: B, D364 | M | - | NA | Direct | > SS | Low
Massage vs. PT | Chronic | NS | Modified Oswestry: B, D364 | M | - | NA | Direct | > SS | Low
Massage vs. PT | Chronic | NS | # of days off from work: B, D364 | M | - | NA | Indirect | > SS | Low
Massage vs. PT | Chronic | NS | VAS: B | M | Precise (2)364,365 | Yes | Direct | > SS | Moderate
Massage vs. PT | Mixed | S | - | - | - | - | - | - | Insufficient
Massage vs. PT | Mixed | NS | - | - | - | - | - | - | Insufficient
Massage vs. PT | Unknown | S | - | - | - | - | - | - | Insufficient
Massage vs. PT | Unknown | NS | - | - | - | - | - | - | Insufficient
Massage vs. ST | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Massage vs. ST | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Massage vs. ST | Chronic | S | - | - | - | - | - | - | Insufficient
Massage vs. ST | Chronic | NS | RMDQ: D90 | M | - | NA | Direct | = S-NS | Low
Massage vs. ST | Chronic | NS | VAS: D90 | M | - | NA | Direct | = S-NS | Low
Massage vs. ST | Chronic | NS | SF-36: D90 | M | - | NA | Direct | = S-NS | Low
Massage vs. ST | Mixed | S | - | - | - | - | - | - | Insufficient
Massage vs. ST | Mixed | NS | - | - | - | - | - | - | Insufficient
Massage vs. ST | Unknown | S | - | - | - | - | - | - | Insufficient
Massage vs. ST | Unknown | NS | - | - | - | - | - | - | Insufficient
Massage vs. Ex | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Massage vs. Ex | Acute/subacute | NS | VAS: B, C361 | M | - | NA | Direct | > SS | Low
Massage vs. Ex | Acute/subacute | NS | RMDQ: B, C361 | M | - | NA | Direct | > SS | Low
Massage vs. Ex | Acute/subacute | NS | ROM (modified Schober test): B,C361 | M | - | NA | Indirect | = S-NS | Low
Massage vs. Ex | Chronic | S | - | - | - | - | - | - | Insufficient
Massage vs. Ex | Chronic | NS | VAS: B41,90 | M | - | Yes | Direct | = S-NS | Moderate
Massage vs. Ex | Mixed | S | - | - | - | - | - | - | Insufficient
Massage vs. Ex | Mixed | NS | - | - | - | - | - | - | Insufficient
Massage vs. Ex | Unknown | S | - | - | - | - | - | - | Insufficient
Massage vs. Ex | Unknown | NS | - | - | - | - | - | - | Insufficient
Massage vs. TENS | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Massage vs. TENS | Acute/subacute | NS | VAS: B101 | H | - | NA | Direct | = S-NS | Low
Massage vs. TENS | Acute/subacute | NS | ROM (Schober’s test: ext, flx): B101 | H | - | NA | Indirect | = S-NS | Low
Massage vs. TENS | Chronic | S | - | - | - | - | - | - | Insufficient
Massage vs. TENS | Chronic | NS | - | - | - | - | - | - | Insufficient
Massage vs. TENS | Mixed | S | - | - | - | - | - | - | Insufficient
Massage vs. TENS | Mixed | NS | - | - | - | - | - | - | Insufficient
Massage vs. TENS | Mixed | NS | - | - | - | - | - | - | Insufficient
Massage vs. TENS | Unknown | S | - | - | - | - | - | - | Insufficient
Massage vs. TENS | Unknown | NS | - | - | - | - | - | - | Insufficient
Massage vs. Relax | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Massage vs. Relax | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Massage vs. Relax | Chronic | S | - | - | - | - | - | - | Insufficient
Massage vs. Relax | Chronic | NS | VAS: B | H | Imprecise (2)370,372 | Yes | Direct | > SS | Low
Massage vs. Relax | Chronic | NS | ROM (flx): B | H | Imprecise (2)370,372 | Yes | Indirect | = S-NS | Low
Massage vs. Relax | Chronic | NS | VAS: B, D369 | M | - | NA | Direct | = S-NS | Low
Massage vs. Relax | Chronic | NS | Oswestry: B, D369 | M | - | NA | Direct | = S-NS | Low
Massage vs. Relax | Chronic | NS | SF-36: B, D369 | M | - | NA | Direct | = S-NS | Low
Massage vs. Relax | Mixed | S | - | - | - | - | - | - | Insufficient
Massage vs. Relax | Mixed | NS | - | - | - | - | - | - | Insufficient
Massage vs. Relax | Unknown | S | - | - | - | - | - | - | Insufficient
Massage vs. Relax | Unknown | NS | - | - | - | - | - | - | Insufficient

S=specific; NS=nonspecific; SS=statistically significant; S-NS=statistically nonsignificant; Man=manipulation; Acu=acupuncture; Ma=massage; Mob=mobilization; PL=placebo; Tx=treatment. Med=medication(s); Int=intervention; PT=physiotherapy; ST=standard therapy; E-acu=electro-acupuncture; MR=muscle relaxation; TENS= transcutaneous electrical nerve stimulation; Ex=exercise; TrP=trigger point; VAS=visual analog scale; RMDQ=Roland Morris Disability scale; NHP=Nottingham Health Profile; PPT= pressure pain threshold; HFAQ=Hanover functional ability questionnaire; MPQ=McGill pain questionnaire; ext=extension; flx=flexion; rot=rotation; PDI=pain disability index; min=minute(s); hr(s)=hour(s); L=low; M=medium; H=high; pt(s)=patient(s); SF=short-form; NPQ=neck pain questionnaire; GWBS=global well-being scale; SLR=straight leg raising; GPE= Global perceived effect; NSAIDS=nonsteroidal antiinflammatory drugs; FTF=finger-to-floor; SF-PQ=short form pain questionnaire; PRI=pain rating index; PPI=present pain intensity

^ψ^ Grade (High, moderate, low, and insufficient)

^£^ Number of pooled trials

B = immediate post-treatment

C = short-term post-treatment

D = intermediate-term post-treatment

E = long-term post-treatment

H = high

L = low

M = medium

- No evidence

= Similar beneficial effect

> Favors treatment A over treatment B

< Favors treatment B over treatment A

><, =>, <= Inconsistent beneficial effect

Population with acute/subacute pain. There were five trials eligible for the inclusion in this sub-section, all of which studied subjects with sub-acute LBP of nonspecific cause.101,360,361,363,366

Subjects with specific pain.

Massage versus placebo. No relevant studies were identified.

Massage versus no treatment. No relevant studies were identified.

Massage versus another type/method of the same CAM. No relevant studies were identified.

Massage versus other treatments. No relevant studies were identified.

Massage versus medication. No relevant studies were identified.

Massage + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Massage versus placebo. In two trials,360,361 the use of massage produced significantly lower immediate or short-term post-treatment pain intensity (VAS, MPQ) and disability scores (Oswestry, RMDQ) compared to placebo (minimal but continuous suction delivered by device,360 and sham laser361). For example, in one of these trials,361 the short-term post-treatment mean RMDQ scores in the massage and placebo groups were 2.86 ± 3.1 and 6.5 ± 4.2, respectively (p < 0.001). The corresponding values for pain intensity on the Pain Rating Index (PRI) were 4.5 ± 5.7 and 7.7 ± 6.0, respectively (p = 0.006). The massage and placebo groups did not differ in post-treatment lumbar ROM.361 One of these trials employed a single treatment design.360

Massage versus no treatment. In one trial,360 the effect of a single massage treatment (roptrotherapy - deep cross-friction massage with a copper myofascial T-bar) was compared to that of ‘no treatment,’ showing significantly decreased pain intensity (VAS: 37.0 ± 19.0 versus 52.0 ± 21.0, p < 0.001) and disability scores (Oswestry: 16.0 ± 5.0 versus 31.0 versus 12.0, p < 0.001) amongst the massage-treated subjects compared to those in ‘no treatment’ group at short-term post-treatment followup (1 week post-treatment).

Massage versus another type/method of the same CAM. No relevant studies were identified.

Massage versus other treatments. Massage was compared to other treatments in four trials.101,361,363,366 In the first trial,361 comprehensive treatment of massage plus exercise and postural education was shown to produce significantly greater short-term post-treatment improvements in pain intensity (PRI, VAS) and disability (RMDQ), compared to massage (soft-tissue manipulation), or remedial exercise alone. In the same trial, immediate or short-term post-treatment lumbar ROM did not differ across the massage, soft-tissue manipulation, and remedial exercise groups. Similarly, in the second trial,101 the magnitude of improvement immediately post-treatment in pain intensity (VAS), extension and flexion (using Schober method), or maximum voluntary extension effort (MVEE) was not significantly different in the massage versus spinal manipulation, TENS, or corset group. In the third trial,363 one year after the end of treatment, subjects who received underwater massage, underwater traction, or balneotherapy did differ in the use of analgesic pills (# taken daily: 2.3 ± 1.7 versus 2.1 ± 1.2 versus 1.9 ± 1.8, respectively) or pain intensity (VAS: 54.7 ± 33.7 versus 45.8 ± 26.2 versus 49.5 ± 25.7, respectively). In the fourth trial,366 acupressure on eight fixed acupoints with aromatic lavender essential oil (performed by a nurse trained in Chinese medicinal nursing) significantly improved short-term post-treatment pain intensity (VAS: 0.61 versus 0.99, p = 0.0001), walking time (in seconds: 0.91 versus 1.03, p = 0.05), and lateral fingertip-to-floor distance (in centimeters: 0.96 versus 1.01, p = 0.01) compared with usual care. There was no significant difference between the two groups for post-treatment pain duration (in hours: 0.76 versus 1.05, p = 0.08).

Massage versus medication. No relevant studies were identified.

Massage + other treatments versus the same other treatments. No relevant studies were identified.

Population with chronic pain. There were 11 trials that were included in this section.29,41,90,347,364,365,368-372 Additional results (acupuncture versus massage) from one trial29 are reported in the Acupuncture, Chronic LBP sub-section. Results of one trial347 are presented in the Mobilization (Chronic LBP) sub-section. All trials included subjects with pain due to nonspecific causes.

Subjects with specific pain.

Massage versus placebo. No relevant studies were identified.

Massage versus no treatment. No relevant studies were identified.

Massage versus another type/method of the same CAM. No relevant studies were identified.

Massage versus other treatments. No relevant studies were identified.

Massage versus medication. No relevant studies were identified.

Massage + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Massage versus placebo. In one trial,368 subjects randomized to massage (reflexology) had numerically similar degree of improvement in intermediate-term post-treatment pain intensity (VAS: 2.2 versus 3.3, MPQ: 6.0 versus 7.5), disability (MRDQ: 4 versus 3.5), and health status (SF-36: physical functioning and bodily pain) compared to subjects in the placebo group. Placebo intervention in this trial included light pressure foot massage which was avoided on the points used for intervention group. Note that this was a pilot study and it was not adequately powered to detect a pre-specified difference.

Massage versus no treatment. The immediate and intermediate-term post-treatment effects of massage (reflexology) and ‘no treatment’ with respect to pain (VAS), disability (Oswestry), global health perception, and physical/social functioning (SF-36) were compared in one trial.369 Although subjects in both groups improved in all outcomes, there was no significant between-group difference after the end of treatment.

Massage versus another type/method of the same CAM. No relevant studies were identified.

Massage versus other treatments. In three trials, massage370,372 or reflexology369 was compared to relaxation therapy in terms of post-treatment reduction in pain intensity (VAS, MPQ), disability (Oswestry), global health perception, physical/social functioning (SF-36), stress (mood , anxiety), and/or lumbar ROM (trunk flexion). In two of the three trials,370,372 massage was shown to produce significantly lower pain intensity, improved depression/anxiety score, ROM, and sleep compared to relaxation therapy, immediately after the end of treatment. In contrast, the third trial369 did not demonstrate any significant immediate (or intermediate-term) post-treatment differences in pain (immediate post-treatment VAS: 50.0 ± 25.7 versus 47.2 ± 26.3), disability (immediate post-treatment Oswestry: 29.8 ± 19.6 versus 33.4 ± 22.3) or physical functioning (SF-36: 53.9 ± 27.8 versus 57.1 ± 30.2 ) between the massage versus relaxation therapy groups. In one trial,90 at 1 year post intervention, the groups receiving exercise followed by Alexander technique lessons (six or 24 lessons plus exercise prescription from a doctor, and counseling from a nurse) significantly improved in disability compared to subjects receiving six sessions of massage (mean difference from baseline in RMDQ: -3.40, 95 percent CI: -4.76, -2.03, versus -1.40, 95 percent CI: -2.77, -0.03 versus -0.58, 95 percent CI: -1.94, 0.77 for 24 and six lessons of Alexander technique, and massage, respectively).

The meta-analyses based on pooled results of two trials370,372 were performed to quantify and compare the effects of massage and relaxation with respect to improving pain intensity (VAS score) and trunk flexion (touch toe without pain in cm) in subjects with chronic nonspecific LBP (Figures 44-45). The result of one meta-analysis indicated a significantly lower pain intensity in the massage compared to relaxation group (pooled mean difference on VAS score: -1.27, 95 percent CI: -2.46, -0.08). Although the difference with respect to trunk flexion was numerically in favor of massage over relaxation, this difference did not reach the traditional level of statistical significance (pooled mean difference: 2.21, 95 percent CI: -1.10, 5.52).

Figure 44 Pain intensity (VAS score) – Immediate post-treatment

Figure 44 depicts a graph of the Pain intensity (VAS score) – Immediate post-treatment. The meta-analyses were performed to quantify and compare the effects of massage and relaxation with respect to improving pain intensity (VAS score) and trunk flexion (touch toe without pain in cm) in subjects with chronic nonspecific lower back pain. Horizontal along the top are rows that correspond to the mean of: Massage; Relaxation; Favors massage negatively; and favors relaxation positively. Two studies, noted vertically, are listed. Horizontally, Field, et, 2007, states number of massage = 15, with the mean being 1.4 (standard deviation) (1.6). The number of relaxation =15, with the mean of 2.7 (standard deviation) (2.4). Favors massage negatively = -1.5. Favors relaxation with the difference in means and a 95% confidence interval is -1.30, (-2.76 (-0.16). Hernandez-Reif, et al, (2001), states number of massage = 12, with the mean being 1.7 (standard deviation) (2.3). The number of relaxation =12, with the mean of 2.9 (standard deviation) (2.8). Favors massage negatively = -1.4. Favors relaxation positively with the difference in means and a 95% confidence interval is -1.20, (-3.25 (-0.85). The pooled results are Massage number = 27, relaxation number = 27, favors massage negatively is about -1.5 and Favors relaxation positively with the difference in means and a 95% confidence interval is -1.27, (-2.46 (-0.08). Heterogeneity: Chi2 = 0.0, df = 1 (P = 0.93); I2 = 0.0%.

Figure 45 Range of mobility (trunk flexion: touch toe without pain) – Immediate post-treatment

Figure 45 depicts a graph of the Range of mobility (trunk flexion: touch toe without pain) – Immediate post-treatment. The meta-analyses were performed to quantify and compare the effects of massage and relaxation with respect to improving pain intensity (VAS score) and trunk flexion (touch toe without pain in cm) in subjects with chronic nonspecific lower back pain. Horizontal along the top are rows that correspond to the mean of: Massage; Relaxation; Favors massage negatively; and favors relaxation positively. Two studies, noted vertically, are listed. Horizontally, Field, et, 2007, states number of massage = 15, with the mean being 61.9 (standard deviation) (8.0). The number of relaxation =15, with the mean of 60.7 (standard deviation) (4.7). Favors massage positively = 0 Favors relaxation with the difference in means and a 95% confidence interval is 1.20, (-3.50 (5.90). Hernandez-Reif, et al, (2001), states number of massage = 12, with the mean being 61.4 (standard deviation) (7.4). The number of relaxation =12, with the mean of 58.2 (standard deviation) (3.6). Favors massage negatively = -0. Favors relaxation positively with the difference in means and a 95% confidence interval is 3.5, (-1.46 (7.86). The pooled results are Massage number = 27, relaxation number = 27, favors massage positively is about 2.5 and Favors relaxation positively with the difference in means and a 95% confidence interval is 2.21, (-1.10 (5.52). Heterogeneity: Chi2 = 0.3, df = 1 (P = 0.55); I2 = 0.0%

The immediate and intermediate-term post-treatment effects of massage (acupressure) and physical therapy (PT) were compared in two trials.364,365 Both trials demonstrated superiority of massage over PT in significantly better scores for pain intensity (VAS, Chinese version of Short-Form Pain Questionnaire – SF-PQ), disability (RMDQ, modified Oswestry questionnaire) or lower number of days off from work (1.5 ± 5.4 versus 3.5 ± 9.3, p < 0.05). In one of these trials,365 the intermediate-term post-treatment mean pain intensity score in the massage group was significantly lower compared to that in the PT group (SF-PQ: 1.08 ± 1.43 versus 3.15 ± 3.62, p = 0.0004). The magnitude of benefit of massage relative to PT did not differ across age and gender groups.365

The meta-analysis of two trials364,365 restricted to subjects with chronic nonspecific low back pain showed a statistically significant difference in favor of massage over physical therapy in reducing pain intensity immediately post-treatment (pooled mean difference on VAS score: -2.11, 95 percent CI: -3.15, -1.07) (Figure 46).

Figure 46 Pain intensity (VAS score) – Immediate post-treatment

Figure 46 depicts a graph of the Pain intensity (VAS score) – Immediate post-treatment. The meta-analysis of two trials was restricted to subjects with chronic nonspecific low back pain showed a statistically significant difference in favor of massage over physical therapy in reducing pain intensity immediately post-treatment (pooled mean difference on VAS score: -2.11, 95 percent CI: -3.15, -1.07). Horizontal along the top are rows that correspond to the mean of: Massage; Physical therapy; Favors massage negatively; and favors relaxation positively. Two studies, noted vertically, are listed. Horizontally, Hsieh et al, 2004, states number of massage = 69, with the mean being 2.3 (standard deviation) (2.6). The number of physical therapy = 77, with the mean of 5.1 (standard deviation) (5.1). Favors massage negatively = 3 Favors relaxation with the difference in means and a 95% confidence interval is -2.8, (-4.14 (1.46). Hsieh et al, 2006, states number of massage = 64, with the mean being 3.2 (standard deviation) (2.1). The number of physical therapy = 65, with the mean of 4.8 (standard deviation) (2.3). Favors massage negatively = -2. Favors physical therapy positively with the difference in means and a 95% confidence interval is -1.7, (-2.48 (-0.92). The pooled results are Massage number = 133, physical therapy number = 132, favors massage positively is about 2.5 and Favors physical therapy negatively with the difference in means and a 95% confidence interval is -2.11, (-3.15 (-1.07). Heterogeneity: Chi2 = 1.9, df = 1 (P = 0.16); I2 = 48.6%.

One trial demonstrated significantly lower pain intensity (VAS) and disability (HFAQ) scores for subjects after receiving acupuncture massage compared to Swedish massage followed by individual exercise.41 In another trial,29 immediate post-treatment symptom bothersomeness scale (p = 0.02) and disability (RMDQ; p < 0.001) scores were better in the massage versus self-care group. After a 1 year followup, these differences were not significant (p = 0.42 and p = 0.97, respectively). In one study,371 subjects who received the combination of massage and specific exercise had a numerically lower immediate post-treatment pain intensity (VAS score) compared to those who received specific or nonspecific exercise alone. In the specific exercise group the post-treatment disability was significantly increased versus pre-treatment disability.

Massage versus medication. No relevant studies were identified.

Massage + other treatments versus the same other treatments. No relevant studies were identified.

Massage versus standard therapy. In one trial,90 the effectiveness of massage was compared to that of normal care in improving pain intensity, disability (RMDQ), and quality of life (SF-36). In this trial, there were significant reductions for all intervention groups in RMDQ disability score and days in pain at 3 months followup. However, no differences were observed in the disability scores between the massage and standard care groups.

Population with mixed duration of pain. This sub-section included three trials.295,362,367 One trial362 included subjects with LBP due to specific cause (i.e., disc herniation), and one trial367 subjects with nonspecific LBP. Results from one trial295 are reported in the Manipulation, Mixed LBP sub-section.

Subjects with specific pain.

Massage versus placebo. No relevant studies were identified.

Massage versus no treatment. No relevant studies were identified.

Massage versus another type/method of the same CAM. No relevant studies were identified.

Massage versus other treatments. In one trial,362 the combination of massage and exercise was as effective as massage alone or more effective than traction in improvement of lumbar function among subjects with LBP due to disc herniation.

Massage versus medication. No relevant studies were identified.

Massage + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Massage versus placebo. No relevant studies were identified.

Massage versus no treatment. No relevant studies were identified.

Massage (type 1) versus massage (type 2). In one trial,367 subjects who received traditional massage (Thai-massage) did not differ from Swedish massage in pain intensity (VAS), disability (Owestry), and back flexion/extension immediately, short-term or log-term period after the end of treatment.

Massage versus other treatments. No relevant studies were identified.

Massage versus medication. No relevant studies were identified.

Massage + other treatments versus the same other treatments. No relevant studies were identified.

Population with unknown duration of pain.

This sub-section included one trial, with subjects having specific LBP.340 Results of this trial are presented in the Mobilization alone (Unknown Duration LBP) sub-section.

Subjects with specific pain.

Massage versus placebo. No relevant studies were identified.

Massage versus no treatment. No relevant studies were identified.

Massage versus another type/method of the same CAM. No relevant studies were identified.

Massage versus other treatments. No relevant studies were identified.

Massage versus medication. No relevant studies were identified.

Massage + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Massage versus placebo. No relevant studies were identified.

Massage versus no treatment. No relevant studies were identified.

Massage versus another type/method of the same CAM. No relevant studies were identified.

Massage versus other treatments. No relevant studies were identified.

Massage versus medication. No relevant studies were identified.

Massage + other treatments versus the same other treatments. No relevant studies were identified.

#### 12 Massage for Treatment of Neck Pain

This section included 14 trials. Two trials were reported in multiple publications(Table 3). Results of two trials are also presented in the Acupuncture, Chronic Duration Neck Pain77 and Mobilization, Chronic Duration Neck Pain353 sections.

Population/trial characteristics. The trials were conducted in Australia (one),43 China, (three)246,247,375 Germany, (one)77 Spain (two),376,377 Taiwan (one),378 Turkey (one),379 United Kingdom (two),380,381 and the United States (three).382-384

All studies included adults of 18 years or older. The proportion of women and men were similar in two studies.375,376 In eight studies, the proportion of women (> 60 percent) was greater than that of men,43,77,377-379,382-384 and in one study, the proportion of men was greater than that of women (> 60 percent).246 In two studies, the proportions of men and women were similar.247,381 The proportion of men/women could not be ascertained for one study.380

In one study, the majority of patients were Caucasians.383 In trials conducted in China, the study participants’ ethnicity was assumed to be Asian,246,247,375 No ethnicity information was reported for the remaining studies.

In total, 1,104 patients were included in these trials and 676 of them were randomized to massage only43,77,246,247,352,376-384 or to massage + other intervention.247,375,378,384 Table 22 presents the control interventions in the included studies.

Table 22 Massage for treatment of neck pain- Control interventions

Type of control group | Cause of Pain | N studies | Detail of Control intervention
1 – Inactive treatments
Placebo/sham | Non Specific | 2 | Sham ultrasound,380,381
| Specific | 2 | Sham laser,77sham myofascial release43
No-treatment/ waiting list | Non Specific | 1 | Similar patient positioning as the massage group with not intervention,377
No-treatment/ waiting list | Specific | 2 | Upright seated position with no intervention,382,384
2 – Active treatments
Usual care | Non Specific | 0 | NA
Usual care | Specific | 1 | Self care: home exercise program followed by moist heat and stretching,382
Education | Non Specific | 1 | Self-care book,383
Education | Specific | 0 | NA
Physiotherapy | Nonspecific | 1 | Massage, therapeutic stretching, and exercise therapy,353
Physiotherapy | Specific | 0 | NA
Physical modalities | Nonspecific | 0 | NA
Physical modalities | Specific | 1 | Hot pack (in multiple groups in combination with massage and other physical modalities),378
Other treatments | Nonspecific | 1 | Control: neither given nor denied treatment,352
Other treatments | Specific | 2 | Traction,375vapo-coolant spray and stretching technique,379
Manual therapy | Nonspecific | 1 | Bone setting,353
| Specific | 0 | NA
Other methods of massage | Nonspecific | 4 | Five session of massage (vs. ),353trigger point pressure release,380myofascial band therapy,381progressive pressure of tender points,377
Other methods of massage | Specific | 1 | Ischemic compression to average pain threshold in three different duration: 30, 60, and 90 seconds (vs. ischemic compression to pain threshold at 30, 60 and 90 seconds),378
Massage in combination with another treatment (vs. acupuncture alone) | Nonspecific | 0 | NA
| Specific | 4 | Needle scalpel therapy,246acupuncture and manipulation,247head traction and extension exercise,384physical modalities,378

NA= not applicable

Number of massage treatment sessions varied and included a single treatment,43,378-381,384 five treatments over 3 weeks,77 up to 10 treatments,247,375,383 18 treatments,382 and 21 treatments246 across all trials.

Risk of bias. The risk-of-bias graph for the trials included in this sub-section is presented in Figure 47. All trials were randomized. The adequate method of randomization and treatment allocation concealment was reported for 38.0 percent and 19.0 percent of the trials, respectively. Only a half of the trials reported that distribution of the subjects’ baseline characteristics across the treatment arms was similar. In 56.0 percent of the trials, study participants were not blinded to the treatment. About 63.0 percent of the trials reported acceptable drop-out rate. Results based on intention-to-treat analysis were explicitly reported for 44.0 percent of the trials. The data for selected items of the risk of bias tool across the CAM interventions (acupuncture; spinal manipulation; spinal mobilization; combination of manipulation and mobilization; and massage therapy) is displayed in table 7.2 of Appendix G.

Figure 47 Risk of bias scores (%)

Figure 47 depicts a graph of the Risk of bias scores (%). On the left hand side listed vertically are Q1 through Q13. A horizontal solid black line represents Yes, a gray line, No, and a dotted line, Unclear. At the bottom, left to right, are the percentages 0%, 20%, 40%, 60%, 80%, and 100%. Q1 is yes 0 to about 40% and Unclear about 41% to 100%. Q2 is yes 0 to about 20%, and Unclear about 21% to 100%. Q3 is yes 0 to about 58%. No, about 59% to about 90%; and Unclear about 91% to 100%. Q4 is yes 0 to about 7%. No, about 8% to about 93%; and Unclear about 94% to 100%. Q5 is yes 0 to about 50%., and Unclear about 51% to 100%. Q6 is yes 0 to about 45%. No, about 46% to about 50%; and Unclear about 51% to 100%. Q7 is yes 0 to about 15% and Unclear about 16% to 100%. Q8 is yes 0 to about 50%, and Unclear about 51% to 100%. Q9 is yes 0 to about 62%. No, about 63% to about 70%; and Unclear about 71% to 100%. Q10 is yes 0 to about 90% and Unclear about 91% to 100%. Q11 is yes 0 to about 45%. No, about 46% to about 75%; and Unclear about 76% to 100%. Q12 is yes 0 to about 70%. No, about 71% to about 95%; and Unclear about 96% to 100%. Q13 is yes 0 to about 10%. No, about 0% to about 7%; and Unclear about 8% to 100%.

Efficacy results. A summary of the key results is presented in table 23. For further detail of the trials please see the evidence tables. (Appendix C, table 2.19 – table 2.26)

Table 23 Key results – Massage therapy for neck pain

CAM therapy | Duration of pain | Cause of pain | Outcome | Risk-of-bias | Precision of the pooled estimate | Consistency | Directness | Finding | GRADE^ψ^
Massage vs. No Tx | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Massage vs. No Tx | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Massage vs. No Tx | Chronic | S | - | - | - | - | - | - | Insufficient
Massage vs. No Tx | Chronic | NS | NPQ: B382 | M | - | NA | Direct | > SS | Low
Massage vs. No Tx | Chronic | NS | ROM (ext, flx): B382 | M | - | NA | Indirect | = S-NS | Low
Massage vs. No Tx | Mixed | S | - | - | - | - | - | - | Insufficient
Massage vs. No Tx | Mixed | NS | - | - | - | - | - | - | Insufficient
Massage vs. No Tx | Unknown | S | PPT: B384 | H | - | NA | Direct | = S-NS | Low
Massage vs. No Tx | Unknown | NS | VAS: B377 | M | - | NA | Direct | > SS | Low
Massage vs. PL | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Massage vs. PL | Acute/subacute | NS | ≥ 2-point decrease on NRS-11: B381 | M | - | NA | Direct | > SS | Low
Massage vs. PL | Chronic | S | VAS: B, C77 | H | - | NA | Direct | > SS | Low
Massage vs. PL | Chronic | S | ROM (ext, flx): B, C, D77 | H | - | NA | Indirect | = NR | Low
Massage vs. PL | Chronic | S | SF-36 (role physical, pain index): D77 | H | - | NA | Direct | = NR | Low
Massage vs. PL | Chronic | NS | - | - | - | - | - | - | Insufficient
Massage vs. PL | Mixed | S | - | - | - | - | - | - | Insufficient
Massage vs. PL | Mixed | NS | - | - | - | - | - | - | Insufficient
Massage vs. PL | Unknown | S | - | - | - | - | - | - | Insufficient
Massage vs. PL | Unknown | NS | PPT: B43 | H | - | NA | Direct | > SS | Low
Massage vs. Ex | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Massage vs. Ex | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Massage vs. Ex | Chronic | S | - | - | - | - | - | - | Insufficient
Massage vs. Ex | Chronic | NS | NPQ: B382 | M | - | NA | Direct | > SS | Low
Massage vs. Ex | Chronic | NS | ROM (ext, flx): B382 | M | - | NA | Indirect | = S-NS | Low
Massage vs. Ex | Mixed | S | - | - | - | - | - | - | Insufficient
Massage vs. Ex | Mixed | NS | - | - | - | - | - | - | Insufficient
Massage vs. Ex | Unknown | S | - | - | - | - | - | - | Insufficient
Massage vs. Ex | Unknown | NS | - | - | - | - | - | - | Insufficient
Massage vs. PT | Acute/subacute | S | - | - | - | - | - | - | Insufficient
Massage vs. PT | Acute/subacute | NS | - | - | - | - | - | - | Insufficient
Massage vs. PT | Chronic | S | - | - | - | - | - | - | Insufficient
Massage vs. PT | Chronic | NS | - | - | - | - | - | - | Insufficient
Massage vs. PT | Mixed | S | - | - | - | - | - | - | Insufficient
Massage vs. PT | Mixed | NS | - | - | - | - | - | - | Insufficient
Massage vs. PT | Unknown | S | - | - | - | - | - | - | Insufficient
Massage vs. PT | Unknown | NS | - | - | - | - | - | - | Insufficient

Tx=treatment. Med=medication(s); Int=intervention; PT=physiotherapy; ST=standard therapy; E-acu=electro-acupuncture; MR=muscle relaxation; TENS= transcutaneous electrical nerve stimulation; Ex=exercise; TrP=trigger point; VAS=visual analog scale; RMDQ=Roland Morris Disability scale; NHP=Nottingham Health Profile; PPT= pressure pain threshold; HFAQ=Hanover functional ability questionnaire; MPQ=McGill pain questionnaire; ext=extension; flx=flexion; rot=rotation; PDI=pain disability index; min=minute(s); hr(s)=hour(s); L=low; M=medium; H=high; pt(s)=patient(s); SF=short-form; NPQ=neck pain questionnaire; GWBS=global well-being scale; SLR=straight leg raising; GPE= Global perceived effect; NSAIDS=nonsteroidal antiinflammatory drugs; FTF=finger-to-floor; SF-PQ=short form pain questionnaire; PRI=pain rating index; PPI=present pain intensity; NA=not applicable

^ψ^ Grade (High, moderate, low, and insufficient)

B = immediate post-treatment

C = short-term post-treatment

D = intermediate-term post-treatment

E = long-term post-treatment

H = high

L = low

M = medium

- No evidence

= Similar beneficial effect

> Favors treatment A over treatment B

< Favors treatment B over treatment A

><, =>, <= Inconsistent beneficial effect

Population with acute/subacute pain. There was one trial evaluating the effectiveness of massage given to patients with subacute neck pain.381

Subjects with specific pain.

Massage versus placebo. No relevant studies were identified.

Massage versus no treatment. No relevant studies were identified.

Massage versus another type/method of the same CAM. No relevant studies were identified.

Massage versus other treatments. No relevant studies were identified.

Massage versus medication. No relevant studies were identified.

Massage + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Massage versus other treatments or placebo. This trial included patients with nonspecific neck pain who were randomized to receive trigger point therapy, myofascial band therapy, or placebo (ultrasound).381 Although the trial authors measured pain intensity (NRS-11, PPT) and cervical ROM, the results were reported on a dichotomous scale (i.e., odds ratios, number needed to treat) instead of continuous scale (i.e., mean scores). The patients treated with trigger point therapy were seven times more likely to improve in terms of pain reduction (decrease of at least two points on NRS-11) compared to patients treated with myofascial band therapy or placebo (odds ratio: 7.4, 95 percent CI: 1.22, 45.02).381

Massage versus no treatment. No relevant studies were identified.

Massage versus another type/method of the same CAM. No relevant studies were identified.

Massage versus other treatments. No relevant studies were identified.

Massage versus medication. No relevant studies were identified.

Massage + other treatments versus the same other treatments. No relevant studies were identified.

Population with chronic pain. A total of four trials restricted to patients with specific (whiplash injuries, myofascial pain syndrome)77,379,382 and nonspecific neck pain,383 were included in this sub-section.

Subjects with specific pain.

Massage versus placebo. In one trial,77 patients with whiplash and myofascial pain syndrome who received massage had lower pain intensity compared to those in sham laser group (VAS: 7.89 versus 17.28, p < 0.05).

Massage versus no treatment. In one trial,382 immediate post-treatment mean NPQ score was significantly lower in the massage group (13.24 ± 11.88) compared with that in no treatment group (35.64 ± 12.54). The patients who received massage had a slight but only numerically greater cervical ROM extension (49.38 ± 13.71) and flexion (50.0 ± 3.74) compared to those who had not received any treatment (extension: 46.80 ± 13.60, flexion: 44.1 ± 12.28).

Massage versus another type/method of the same CAM. No relevant studies were identified.

Massage versus other treatments. There was one trial evaluating the clinical benefits of massage compared with vapocoolant spray in the treatment of patients with chronic myofascial pain syndrome.379 The application of massage did not differ from vapocoolant spray in reducing immediate post-treatment pain on VAS (2.60 ± 1.73 versus 2.88 ± 1.50) or increasing cervical ROM (flexion, extension). The only significant difference was observed for rotation to left in favor of spray versus massage (78.65 versus 72.45, p < 0.05).379

In another trial,382 immediate post-treatment mean NPQ score was significantly lower in the massage group (13.24 ± 11.88) compared to that in the exercise group (20.23 ± 12.06). In this trial, patients who received massage had a slight but only numerically greater cervical ROM extension (49.38 ± 13.71) and flexion (50.0 ± 3.74) compared to those who received exercise (extension: 48.38 ± 11.8, flexion: 48.62 ± 14.04).

Massage versus medication. No relevant studies were identified.

Massage + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Massage versus placebo. No relevant studies were identified.

Massage versus no treatment. No relevant studies were identified.

Massage versus another type/method of the same CAM. No relevant studies were identified.

Massage versus other treatments. In one trial,383 there was no difference in immediate and intermediate-term post-treatment degree of disability between patients who received 10 weeks of massage and self-care instruction (16 weeks post-treatment difference in NDI mean score: -1.9, 95 percent CI: -4.4, 0.63, p = 0.14). At 16 weeks post-treatment, the use of medication, which was similar in the groups at baseline, increased by 14.0 percent in the self-care group but did not change in the massage group.383

Massage versus medication. No relevant studies were identified.

Massage + other treatments versus the same other treatments. No relevant studies were identified.

Population with mixed duration of pain. A total of six trials restricted to patients with specific (whiplash injury, spondylosis, spondylopathy, myofascial pain syndrome)246,247,375,376 and nonspecific380 neck pain of mixed duration (acute, sub-acute, chronic) were included in this section.

Subjects with specific pain.

Massage versus placebo. No relevant studies were identified.

Massage versus no treatment. No relevant studies were identified.

Massage versus another type/method of the same CAM. No relevant studies were identified.

Massage versus other treatments. No relevant studies were identified.

Massage versus medication. No relevant studies were identified.

Massage + other treatments versus the same other treatments. No relevant studies were identified.

Massage alone versus massage (combined or alone). In one trial,376 40 patients with myofascial pain syndrome experienced equal immediate post-treatment clinical benefit in terms of pain intensity reduction after being randomized to receive either ischemic compression (PPT: 2.2 ± 0.6 and VAS: 3.8 ± 0.9) or transverse friction massage (PPT: 2.35 ± 0.4 and VAS: 4.2 ± 0.4; for both outcomes between-group p > 0.40).

In two trials246,247 of patients with spondylosis or spondylopathy, massage combined with either acupoint injection247 or needle scalpel246 produced statistically significantly greater rates of cure (post-treatment absence of symptoms and physical signs) compared with massage alone.

Massage + other treatment versus other treatment. In one Chinese study,375 the combination of massage and traction was compared to traction alone in subjects with spondylopathy. The immediate post-treatment improvement score (measured using Cervical Spondylopathy Therapeutic Effect Rating Scale) but not effective rate (subjects with improved clinical and body symptoms but partially affected daily activities) was significantly higher in the massage combination versus traction alone group (0.50 ± 0.16 versus 0.36 ± 0.14, p < 0.01).

Subjects with nonspecific pain.

Massage versus placebo. No relevant studies were identified.

Massage versus no treatment. No relevant studies were identified.

Massage (type 1) versus massage (type2). In one trial,380 the effectiveness of ischemic compression and trigger point pressure release was compared. In this trial, patients had similar post-treatment pain intensity (VAS, PPT) across the randomized groups. For example, the effect on mean VAS scores was similar (p > 0.10) for patients treated with ischemic compression (22.9 r 12.7) versus sham ultrasound (22.6 r 8.2). Likewise, no between-group differences (p > 0.10) were found in relation to the mean pain pressure threshold (PPT) scores (4.45 r 1.69 versus 3.77 r 1.76 versus 3.37 r 1.62).380

Massage versus other treatments. No relevant studies were identified.

Massage versus medication. No relevant studies were identified.

Massage + other treatments versus the same other treatments. No relevant studies were identified.

Population with unknown duration of pain. A total of four studies were included which enrolled patients with specific (myofascial trigger point syndrome),43,378,384 or nonspecific cause.377

Subjects with specific pain.

Massage versus placebo. In one trial,43 the application of manual pressure to trigger points (to patient’s pain tolerance level) sustained for 60 seconds resulted in a statistically greater improvement compared to sham myofascial release (p < 0.001).

Massage versus no treatment. No relevant studies were identified.

Massage versus no treatment. No relevant studies were identified.

Massage (type 1) versus massage (type 2). In one trial,384 single treatment with either occipital release (O/R), active head retraction with extension exercises , or no treatment did not differ in reducing sensitivity (PPT in kg/cm^2^) of cervical and scapular trigger points (2.5 ± 1.1 versus 2.8 ± 1.3 versus 2.6 ± 1.5, p = NR).

In another trial,378 immediate effects of ischemic pressure applied at two intensities (low pressure = at pain threshold, high pressure = at averaged pain threshold and tolerance) were measured. The use of ischemic compression therapy with low pressure (90 seconds) and high pressure (60 – 90 seconds) was associated with a significant reduction of pain (VAS), elevation of pain tolerance, and improvement of ROM compared to that of ischemic compressions with low or high pressure at shorter durations (p < 0.05).

Massage versus other treatments. No relevant studies were identified.

Massage versus medication. No relevant studies were identified.

Massage + other treatments versus the same other treatments. No relevant studies were identified.

Subjects with nonspecific pain.

Massage versus placebo. No relevant studies were identified.

Massage versus no treatment. In one trial,377 both classical and modified strain/counterstrain techniques produced significantly better immediate post-treatment pain intensity scores (VAS) compared to no treatment in subjects with nonspecific neck pain (p < 0.001). The ‘no treatment’ group in this study did not experience any change from baseline in the pain intensity measure (p > 0.30).

Massage (type 1) versus massage (type2). In one trial,377 local pain elicited by application of 4.5 kg/cm^2^ of pressure on the tender points improved after a single treatment with either classical or modified strain/counterstrain technique in subjects with nonspecific neck pain. However, the difference in immediate post-treatment VAS scores between the two classical and modified strain/counterstrain groups was not statistically significant (p = 0.8).

Massage versus other treatments. No relevant studies were identified.

Massage versus medication. No relevant studies were identified.

Massage + other treatments versus the same other treatments. No relevant studies were identified.

### Cost Effectiveness

In total 10 trials were included for cost-effectiveness of CAM treatment for LBP24,72,94,112,125,385,386, and neck pain.63,89,130 The trials recruited patients with nonspecific pain (Table 24 and 25).

Table 24 Summary of RCTs reporting data on economic evaluation of CAM versus other treatments- Low back pain

Author, Year Country of Study | N (sample size) Region, Cause, Duration of Pain | Intervention/s | Outcomes Duration of Outcome Assessment | Conclusion (by study authors)
Hollinghurst, S ATEAM study (2008)90,94 UK | N= 579 LBP, N-S; Chronic | - Intervention: massage, and six or 24 lessons in the Alexander technique.; - Control: Normal care (control); 50% of each group randomized to exercise (by GP) + behavioral counseling (by a nurse) | Costs to NHS & cost to participants (incremental cost effectiveness ratios & cost effectiveness acceptability curves) 1 year | The acceptability curves showed that if exercise is the first choice, at a threshold of GBP $18,000 per QALY the chance that a second intervention is cost-effective is 80% Exercise had the highest probability of being the most cost-effective first choice of therapy.
Kominski, GF (2005)66,70-76,387 U.S. | N = 681 LBP, N-S; Acute/subacute | - medical care only (MD); - medical care withphysical therapy (MD + PT),; - chiropractic care (CC); - CC + physical modalities (Pm) | Total outpatient costs (excluding pharmaceuticals, and productivity loss) Cost-effectiveness analysis was not performed 18 months | Adjusting for covariates, cost for CC 51.9% grater than MD; CC + Pm 3.2% grater than CC; and MD + PT 105.8% grater than MD Higher costs for CC without producing better clinical outcomes
Niemisto, L (2003)385 Finland | N = 204 LBP, N-S, Chronic | - SM + MD; - Physician consultation + educational booklet | Total healthcare cost Productivity loss (full day or half day salary) 1 year | The incremental cost of SM + MD compared with the physician consultation for one point improvement on pain intensity (100 mm VAS) = $23. No SS differences in cost between two groups
Seferlis, T (2000)386,388 Sweden | N = 180 LBP w/out sciatica requiring sick leave; N-S; Acute | - General Practitioner care (GP); - Manual therapy (MT); - Intensive training program | Total (direct & indirect) cost per patient Method used: least-cost alternative, i.e. a cost-minimization analysis 1 year | There were no differences between the three tx groups in total cost, with GP being the least costly. Indirect costs, defined as sick-leave for LBP represent about 90% of the total cost
Ratcliffe (2006) 110-118,389 U.K. | N= 241 LBP; N-S; Mixed duration | - Acupuncture (Acu); - Usual care (UC) | Total NHS cost Incremental cost pr QALY 2 years | Total costs to the U.K. health service were higher on average for the Acu ($859) than for the UC ($645) Acu tx has > 90% chance of being cost effective at a $37,400 cost per QALY threshold.
UK BEAM trial team (UK beam study123,125,390 U.K. | N = 1287 LBP; N-S; Mixed duration | - Spinal manipulation (SM) + best care by general practitioner care (GP); - SM + exercise; - GP + exercise; - GP alone | Healthcare costs Quality adjusted life QALY Cost per QALY 1 year | All three active txs increased pts’ average QALYs compared with GP alone. SM + GP care appears relatively cost-effective compared to GP care alone from the health sector’s perspective.
Witt, CM (2006)24-26 Germany | N = 2841 LBP; N-S; Chronic | - Acupuncture (Acu) + routine care; - No tx (delayed acu) +routine care | The incremental cost effectiveness ratio 6 months | The incremental cost-effectiveness ratio was $15,895 per QALY At a threshold of $22,662 per QALY acu had a more than 90% chance of being cost-effective.

RCT= randomized control trial; LBP = low back pain; AT= Alexander technique; NS = non specific; Acu = acupuncture; TENS = transcutaneous electrical stimulation; tx = treatment; GP= general practitioner (care); PT= physical therapy; QALY= quality adjusted life years; MD=medical care; w/out=with or without; Pm=physical modalities; HRQoL=health related quality of life; NHS = National Healthcare Services; SS = statistically significant; U.K.= United Kingdom

Table 25 Summary of RCTs reporting data on economic evaluation of CAM versus other treatments- Neck pain

Author, Year Country of Study | N (sample size) Region, Cause, Duration of Pain | Intervention/s | Outcomes Duration of Outcome Assessment | Conclusion (by study authors)
Willich, SN (2006)130,131 Germany | N = 3451 NP, N-S; Chronic | - Acupuncture (Acu) + routine care; - routine care | Direct and indirect cost (not including private medical expenses) The incremental cost-effectiveness ratio of acu tx 3 months | The incremental costs-effectiveness ratio was $15.710 per QALY; the net benefit of acup was $1147.
Lewis, M (2005)89,92 U.K. | N = 350 NP, N-S; Mixed | - advice and exercise (A&E)+ manual tx (MT); - advice and exercise + pulsed shortwave diathermy (PSWD); - advice and exercise alone | Health care & societal costs QALY utility scores 6 months | Probability of each intervention being cost-effective at the $48,000 per QALY threshold Health care perspective-: MT = 0.37, PSWD = 0.31, and A&E = 0.32 Societal perspective- MT = 0.44, PSWD = 0.26, and A&E = 0.30 PWSD was the last cost effective of three tx strategies
Kothals de Bos (2005)63,64 the Netherlands | N = 183 NP; N-S; Mixed | - Spinal mobilization (SM); - Physiotherapy (PT); - General practitioner care (GP) | Direct and indirect costs Cost effectiveness, and cost utility ratios were evaluated 1 year | The total costs of MT were around one third of the costs of PT, or GP MT was less costly and more effective than PT, or GP

RCT= randomized control trial; NP= neck pain; NS = non specific; Acu = acupuncture; TENS = transcutaneous electrical stimulation; tx = treatment; GP= general practitioner; PT= physical therapy; QALY= quality adjusted life years; MD=medical care; w/out=with or without; Pm=physical modalities; HRQoL=health related quality of life; NHS = National Healthcare Services; SS = statistically significant; UK= United Kingdom

#### Low Back Pain

We identified 10 studies.24,29,72,94,112,125,224,278,385,386 Of these 10 studies, seven were reports of full economic evaluations of the cost-effectiveness of spinal manipulation72,125,385,386, acupuncture,24,112 and massage94 for low back pain. The three remaining studies had not performed a full economic evaluation by combining differences in costs and effects of the two (or more) compared alternatives and therefore were excluded from the review.29,224,278

Population/trial characteristics. The studies were conducted in Finland,385 Germany,24 Sweden,386 United Kingdom,94,112,125 and United States.72 The mean age ranged from 37 to 54 years and the proportion of men and women were balanced in all trials. In total, 5,984 participants with nonspecific LBP were included in these seven trials. The duration of pain was acute in one trial,386, chronic in three trials,24,94,385 and mixed in three trials.72,112,125

Acupuncture. Ratcliffe et al,112 compared individualized acupuncture treatment for 3 months from acupuncturists trained in traditional Chinese medicine with usual care. The study population consisted of patients with subacute and chronic low back pain. The total costs of health care utilization during 2 year followup were higher in the acupuncture group ($859) compared with the usual care group ($645). The difference in health gain was .012 QALY at 1 year and 0.027 QALY at 2 year followup. The incremental cost-utility ratio was $7931 per QALY gained. From the health services perspective, the acceptability curve showed that acupuncture had a more than 90 percent chance of being cost-effective at a $37,400 (GBP 20,000) per QALY threshold. The study showed that, from societal perspective (including costs of health care utilization, patient costs and costs of productivity losses) acupuncture was more dominant (i.e. less costly and more effective) compared with GP care.

Witt et al,24 conducted an economic evaluation alongside a large randomized trial (N=3093) comparing acupuncture with no treatment (delayed acupuncture) in patients with chronic low back pain. The difference in QALYs at 3 months between the acupuncture and control group was 0.03. The costs of acupuncture were higher than the costs of the control group; mean difference at 3 months was $423 (95 percent CI: 224, 622) in total costs, and $461 (95 percent CI: 342, 579) in back pain specific costs. The incremental cost-utility ratios were $15,895 (Euro 10,526) per QALY gained for overall costs and $17,321 (Euro 11,470) per QALY gained for back pain specific costs. At a threshold of $22,662 (Euro 15,000) per QALY acupuncture had a more than 90 percent chance of being cost-effective.

Spinal manipulation. Four full economic evaluations on spinal manipulation were identified.72,125,385,386 In a large randomized control study72 that recruited patients from a large medical group practices (HMO), the authors compared four treatments: chiropractic care (spinal manipulation), chiropractic care plus physical modalities (heat, cold, ultrasound, and electrical muscle stimulation provided by chiropractor), medical care, and medical care plus physical therapy. (Table 22) The study population consisted of 681 acute, subacute or chronic low back pain patients. The authors conducted a cost-minimization analysis, given that that previously published findings showed no clinically meaningful difference in effects between these four treatments. The results showed that the adjusted mean outpatient costs of low back pain in 18 months were $765 for medical care plus physical therapy, $565 for chiropractic plus physical modalities, $550 for chiropractic, and $463 for medical care. The authors concluded that costs were higher for chiropractic care compared with medical care without producing better clinical outcomes. Physical therapy in addition to medical care does not seem to be a cost-effective strategy for low back pain. However, the authors did not include in their analyses pharmaceutical costs and costs of production loss.

Niemisto,385 compared a combined intervention of physician consultation, spinal manipulation and stabilizing exercises to physician consultation alone in 204 patients with chronic low back pain. The economic evaluation was conducted from a societal perspective. Costs of health care consumption and costs of productivity loss were included. There were no statistically significant differences in costs between the two groups. The incremental cost of the combination treatment compared with the physician consultation only for one point improvement on pain intensity (100 mm VAS) was $23.

Seferlis et al,386 conducted a cost-minimization analysis of manual therapy, general practitioner care, and intensive training, since a previously conducted randomized trial had not identified any statistically significant differences in clinical effects between the three interventions. The study population consisted of patients with acute low back pain. Direct and indirect costs were included. The results showed that direct costs per patient were $1,054 for manual therapy, $404 for GP care, and $1,123 for intensive therapy. Indirect costs per patient were $6,163 for manual therapy, $7,072 for GP care, and $5,556 for intensive therapy. Finally, the total costs per patient were $7,217 for manual therapy, $7,476 for GP care, and $6,680 for intensive therapy. This study did not report any quality of life or additional cost of drug outcomes. There were no statistically significant differences in costs between the groups.

The UK BEAM trial,125 compared the cost-effectiveness of adding spinal manipulation, exercise classes, or manipulation followed by exercise (combined treatment) to “best care” in general practice for patients with subacute and chronic low back pain. Results showed that adding spinal manipulation to GP care was effective in improving QALY compared to GP care alone, and would cost $ 8880 per QALY gained from the health sector’s perspective. In contrast, adding both spinal manipulation and exercise to GP care did not statistically significant improve QALY compared to GP care alone, but would only cost $7030 per QALY gained. The authors concluded that spinal manipulation in addition to GP care appeared relatively cost-effective compared to GP care alone from the health sector’s perspective.125

Massage. Hollinghurst et al,94 reported an economic evaluation of therapeutic massage, exercise, Alexander technique and usual GP care in patients with chronic and recurrent low back pain. The authors used a 4 X 2 factorial design in which participants were randomized to one of eight groups. Total NHS costs over 1 year (costs of interventions, GP visits, other primary and secondary care, and medication) were $460 (± 364) for the massage group (n=64), $97 (± 179) for GP care without exercise (n=60), $388 (± 260) for 6 sessions of Alexander technique without exercise (n=53), $1,087 (± 467) for 24 sessions of Alexander technique without exercise (n=61), $427 (± 190) for 6 sessions of Alexander technique with exercise (n=57), $1,177 (± 585) for 24 sessions of Alexander technique with exercise (n=56), $476 (± 647) for massage with exercise (n=56), and $275 (± 932) for GP care with exercise (n=51). Exercise had the highest probability of being the most cost-effective first choice of therapy. The acceptability curves showed that if exercise is the first choice, at a threshold of GBP $18,000 per QALY, the chance that a second intervention is cost-effective is 80 percent.

#### Neck Pain

Three full economic evaluations were identified that evaluated the cost-effectiveness of spinal manipulation,63,89 and acupuncture130 for neck pain.

These trials were reported in multiple publications62,63;89,92;and 130,131 (Table 23)

Population/trial characteristics. The trials were conducted in Germany,130, the Netherlands,63 and the United Kingdom.89 In total, 3,984 participants with mixed nonspecific neck pain were included. The mean age of participants ranged from 45 to 53 years and the proportions of men and women were not significantly different in any of these trials.

Acupuncture. Willich et al,130 performed cost-effectiveness and cost-utility analyses alongside a randomized controlled trial comparing additional acupuncture compared with usual care alone in patients with chronic neck pain. Subjects in the usual care group received acupuncture treatment after the 3 months study period. Adults with chronic neck pain (> 6 months) were included. A total of 3,451 subjects were randomized to either acupuncture (n=1,753) or usual care (n=1,698). The mean (SD) QALYs over 3 months followup were 0.649 (0.096) in the acupuncture group and 0.625 (0.103) in the usual care group, with a mean difference of 0.024 (p=0.004). Acupuncture treatment was associated with significantly higher total costs over 3 months of followup compared to usual care ($1,157 versus $810); the mean difference in total costs was $347 (95 percent CI: 220, 477). This difference in cost was mainly due to costs of acupuncture ($452). The incremental costs-effectiveness ratio was $15.710 per QALY; the net benefit of acupuncture was $1147.

Spinal manipulation. Lewis et al,89 conducted cost-effectiveness and cost-utility analyses alongside a randomized controlled trial (Diedzic et al) comparing advice and exercise plus manual therapy (n=114) and advice and exercise plus pulsed shortwave diathermy (n=121) with advice and exercise alone (n=115) for patients with nonspecific neck pain. Experienced physiotherapists provided all interventions. The results showed that the mean improvement in neck pain (VAS) at 6 months was 10.2 in the manual therapy group, 10.3 in the pulsed shortwave diathermy group and 11.5 in the advice and exercise group. The mean quality adjusted life years (QALY) scores for the treatment three groups were 0.342, 0.360, and 0.362, respectively. The mean health care costs were $190, $197 and $169 and the mean total costs were $486, $543 and $598, respectively. From the health care perspective, the cost-effectiveness acceptability curves showed that the probability of each intervention being cost-effective at the $48,000 per QALY threshold was 0.37 for manual therapy, 0.31 for pulsed shortwave diathermy and 0.32 for advice and exercise alone. From the societal perspective, these probabilities were 0.44, 0.26 and 0.30, respectively. Although the authors concluded that the interventions of choice are likely to be manual therapy or advice and exercise alone, and that pulsed shortwave diathermy is unlikely to be a cost-effective intervention, the probabilities that any of these interventions is cost-effective are very low.

Korthals-de Bos et al,63 conducted an economic evaluation alongside a randomized controlled trial (Hoving et al)62 to evaluate the cost effectiveness of manual therapy (n=60), physiotherapy (individualized exercise therapy, active and postural or relaxation exercises, stretching, and functional exercises; n=59), and care by a general practitioner (n=64) for subjects with nonspecific neck pain. Study participants were treated by the general practitioners, physiotherapists, or manual therapists. Manual therapy provided faster improvement compared with physiotherapy and general practitioner care up to 26 weeks, but there were no statistically significant differences at 52 weeks of followup. The total costs of manual therapy ($402) were around one third of the costs of physiotherapy ($1,166) and general practitioner care ($1,240). These differences were statistically significant for manual therapy versus physiotherapy and manual therapy versus general practitioner care, but not for general practitioner care versus physiotherapy.

## KQ1a-b For any of the CAM Therapies Found to be Effective for Back Pain, what Patient, Treatment Provider and Trial Specific Factors Influence Success of Treatments?

### Subgroup Analysis

The amount of evidence regarding factors potentially influencing treatment effect (e.g., age, gender race, education, income, cause of pain, type of treatment provider, dose of treatment) was relatively limited. Effects of treatment related factors such as duration, frequency (number of sessions) are explored qualitatively if reported in the efficacy and effectiveness sections for dose response studies (see Chapter 3).

Qualitative analysis. We identified only seven trials that included age-specific populations (i.e., elderly),45,53,207,208,216,217,226,227 Six trials that included women only219,263 or men only.144,284,349 (seeTable 26). Of these, nine trials were conducted to assess the effects of acupuncture in subjects with low back pain.53,144,207,208,216,217,219,226,227 The results of trials across these subgroups were not comparable due to different control treatments and/or duration/cause of pain in subjects included in these trials.

Table 26 Subgroup analyses

Body region Intervention | Elderly | | Only women | | Only men
Body region Intervention | No. of studies | Outcomes (efficacy) | No. of studies | Outcomes (efficacy) | No. of studies | Outcomes (efficacy)
LBP Acupuncture | 7^53,207,208,216,217,226,227^ | Pain (VAS)53,207,208,216,217,226,227, Disability (RMQ)207,208,216,217,226 QOL53,226 | 1^219^ | Pain (VAS) QOL | 1^144^ | Pain + ability to return to work
NP Acupuncture | 1^45^ | Pain (VAS) | 1^263^ | Pain (VAS) Function (NHP)
Cervicogenic headache Acupuncture | None | NA | None | NA | None | NA
LBP Manipulation | None | NA | None | NA | 1^284^ | NA
Cervicogenic headache Manipulation | None | NA | None | NA | None | NA
LBP Mobilization | None | NA | None | NA | 1^349^ | Pain (VAS)
NP Mobilization | None | NA | None | NA | None | NA
LBP Massage | None | NA | None | NA | None | NA
NP Massage | None | NA | None | NA | None | NA
All | 8 | 14 | 2 | NA | 3 | 0

Abbreviations: NA=not applicable; LBP= low back pain; NP= neck pain; VAS=visual analogue scale; PPT=Pressure Pain Threshold; NHP=Nottingham Health Profile;

In one trial reporting subgroup effects of manipulation in subjects with mixed duration of low back pain.34,81 The subject’s age, gender, symptom duration, or the therapist’s years of experience did not have a significant effect on the mean change for Oswestry score between two groups receiving spinal manipulation in addition to exercise and exercise alone. Within the spinal manipulation group, subjects positive on the rule (4/5 of the above criterion) had a significantly greater improvement on Oswestry score compared to subjects negative on the rule (immediately and short-term post-treatment: 10.3, 95 percent CI: 2.2, 18.4, p < 0.014).81 In the same study, patients with LBP of mixed duration who were judged to have lumbar hypomobility experienced greater benefit from spinal manipulation than subjects without hypomobility (mean difference, 23.7 percent, 95 percent CI: 5.1, 42.4). Subjects with lumbar hypermobility receiving a program of stabilizing exercise had a greater benefit than subjects without hypermobility (mean difference, 36.4 percent, 95 percent CI: 10.3, 69.3).34

In one trial reporting subgroup analysis of subjects with chronic nonspecific low back pain,365 the beneficial effect of massage compared to physical therapy (physical modalities, exercise and traction) was similar across age (≤ 50 years: p = 0.0023 and > 50 years: p = 0.0221) and gender groups (male: p = 0.0356, female: p = 0.001). However, the short term post-treatment effect of massage differed across baseline pain severity groups (VAS ≤ 8: p = 0.179, and VAS > 8: p = 0.0001). Specifically, massage was significantly better in reducing pain intensity compared to physical therapy but only in subjects with severe pain at baseline (immediately post-treatment mean VAS: 2.84 ± 3.13 versus 8.19 ± 5.60, p = 0.0001). The intermediate-term (6 months post-treatment followup) effect of massage compared to physical therapy was significantly more beneficial and was not different across the severity groups (VAS ≤ 8: p = 0.0319, and VAS > 8: p = 0.0016).

Quantitative analysis. We were not able to conduct the analysis quantitatively due to insufficient data. The largest meta-analysis of this review included only 10 trials (acupuncture versus placebo for chronic nonspecific low back pain; (seeFigure 4) and the remaining smaller meta-analyses included a range of two to four trials. The pooled trials did not include solely subjects from the subgroups of interest.

### Sensitivity Analyses

The conduct of sensitivity analysis was possible for only one meta-analysis (Figure 4) with pooled mean difference -0.59, 95 percent CI: -0.93, -0.25). We explored the impact of study quality (risk-of-bias) on the pooled effect estimate of mean pain score difference between acupuncture and placebo. Initially, the 10 trials were categorized into two groups: ‘higher risk-of-bias’ and ‘lower risk-of-bias.’ If for a trial, seven or more items of the risk-of-bias tool were rated as ‘Yes’ this trial was categorized into ‘lower risk-of-bias’ group, otherwise into ‘higher risk-of-bias’ group. Thus, there were four ‘lower risk-of-bias’ trials22,37,197,206 and six ‘higher risk-of-bias’ trials.99,141,156,198,203,228 The pooled effect estimates for the two categories of trials were -0.43 (95 percent CI: -0.76, -0.09) and -0.75 (95 percent CI: -1.39, -0.11), respectively (Figures 48-49). This analysis suggests that the quality (risk of bias) of trial did not appreciably modify the effect of acupuncture compared to placebo in subjects with chronic nonspecific low back pain.

Figure 48 Pain intensity (VAS Score) – Immediate post-treatment (lower risk-of-bias trials)

Figure 48 is a graph depicting Pain intensity (VAS Score) – Immediate post-treatment (lower risk-of-bias trials). We explored the impact of study quality (risk-of-bias) on the pooled effect estimate of mean pain score difference between acupuncture and placebo Horizontal along the top are rows that correspond to the mean of: Acupuncture; Placebo; Favors acupuncture negatively; and favors placebo positively. Four studies and pooled results are noted vertically. Horizontally, Brinkhaus et al, 2006, states number of acupuncture = 140, with the mean being 3.5 (standard deviation) (2.9). The number of placebo = 70, with the mean being 4.4 (standard deviation) (3). Favors acupuncture negatively = around 1. Favors placebo with the difference in means and a 95% confidence interval is -0.92, (-1.75 (-0.09). Inoue et al, 2006, states number of acupuncture = 24, with the mean being 3.3 (standard deviation) (0.7). The number of placebo = 16, with the mean of 5.5 (standard deviation) (1.3). Favors acupuncture negatively = -1. Favors placebo positively with the difference in means and a 95% confidence interval is -0.8, (-1.54 (-0.06). Kwon et al, 2007, states number of acupuncture = 15, with the mean being 4.7 (standard deviation) (0.7). The number of placebo = 28, with the mean of 3.6 (standard deviation) (1.5). Favors acupuncture negatively = less than 0. Favors placebo positively with the difference in means and a 95% confidence interval is -0.25, (-1.13) (-0.63). Haake et al, 2007, states number acupuncture = 370, with the mean being 4.9 (standard deviation) (1.9). The number of placebo = 375, with the mean of 5.1 (standard deviation) (1.9). Favors acupuncture negatively = -1. Favors placebo positively with the difference in means and a 95% confidence interval is -0.24, (-0.51 (-0.03).The pooled results are acupuncture number = 549, placebo number = 489, favors acupuncture negatively is about -1 and Favors placebo positively with the difference in means and a 95% confidence interval is -0.43, (-0.76 (-0.09). Heterogeneity: Chi2 = 3.92, df = 3 (P = 0.27); I2 = 23.5%.

Figure 49 Pain intensity (VAS score) – Immediate post-treatment (higher risk-of-bias trials)

Figure 49 is a graph depicting Pain intensity (VAS score) – Immediate post-treatment (higher risk-of-bias trials). We explored the impact of study quality (risk-of-bias) on the pooled effect estimate of mean pain score difference between acupuncture and placebo Horizontal along the top are rows that correspond to the mean of: Acupuncture; Placebo; Favors acupuncture negatively; and favors placebo positively. Six studies and pooled results are noted vertically. Horizontally, Mendelson et al, 1983, states number of acupuncture = 36, with the mean being 3 (standard deviation) (1.8). The number of placebo = 70, with the mean being 4.4 (standard deviation) (3). Favors acupuncture negatively = around 1. Favors placebo with the difference in means and a 95% confidence interval is -0.92, (-1.75 (-0.09). Inoue et al, 2006, states number of acupuncture = 24, with the mean being 3.3 (standard deviation) (0.7). The number of placebo = 41, with the mean of 4 (standard deviation) (2.4). Favors acupuncture negatively = -1. Favors placebo positively with the difference in means and a 95% confidence interval is . -0.98 (-1.95 (-0.01). Leibling et al, 2002, states number of acupuncture = 40, with the mean being 3.2 (standard deviation) (2.2). The number of placebo = 28, with the mean of 3.6 (standard deviation) (1.5). Favors acupuncture negatively = -1. Favors placebo positively with the difference in means and a 95% confidence interval is -1.1, (-2.1) (-0.1). Molsberger et al, 2002, states number acupuncture = 58, with the mean being 2.6 (standard deviation) (2.1). The number of placebo = 58, with the mean of 3.6 (standard deviation) (1.9). Favors acupuncture negatively = -1. Favors placebo positively with the difference in means and a 95% confidence interval is -1, (-1.73 (-0.27). Kerr et al, 2003, states number acupuncture = 26, with the mean being 5.1 (standard deviation) (2.2). The number of placebo = 20, with the mean of 6.2 (standard deviation) (3.1). Favors acupuncture negatively = -1. Favors placebo positively with the difference in means and a 95% confidence interval is -1.04, (-2.57. (0.49). Fu et al, 2006, states number acupuncture = 32, with the mean being 2.6 (standard deviation) (2.6). The number of placebo = 28, with the mean of 3.8 (standard deviation) (2.3). Favors acupuncture negatively = -1. Favors placebo positively with the difference in means and a 95% confidence interval is -1.23, (-2.48 (-0.02). Cherkin et al, 2009, states number acupuncture = 158, with the mean being 3.3 (standard deviation) (2.5). The number of placebo = 162, with the mean of 3 (standard deviation) (2.4). Favors acupuncture negatively = less than +1. Favors placebo positively with the difference in means and a 95% confidence interval is 0.3, (-2.4 (0.84). The pooled results are acupuncture number = 345, placebo number = 349, favors acupuncture negatively is about -1 and Favors placebo positively with the difference in means and a 95% confidence interval is -0.75, (-1.39 (-0.11). Heterogeneity: Chi2 = 14.5, df = 5 (P = 0.01); I2 = 65.4%.

## KQ1c Does the Use of any of the Three Most Prevalent Types of CAM for Back Pain in Adults Result in a Decreased or Increased Utilization of Conventional Management?

### Low Back Pain

The comparative data on days off work, medication use, and health care utilization reported for 16 trials of low back pain are presented in Tables 27-29.^22,24,29,31,53,66,95,111,112,143,202,342,346,369,385,391^

Table 27 Utility of conventional medicine for low back pain: Use of medication

Author, Year (ID) | Intervention (sample size) | Control (sample size) | Region, Cause, duration of Pain | Healthcare Utilization- end point | Results CAM | Results Control | CAM vs. Control
Acupuncture
Brinkhaus 2006^22^ | Acupuncture (147) | Placebo (minimal acupuncture); waiting list (154) | LBP, N-S | Days with analgesics in last 4 week-immediately post intervention (8 weeks) | 2.0 (4.8) | 4.9 (8.3); 6.2 (1.6) | Acupuncture vs. minimal acupuncture -2.9 (95%CI: -5.0, -0.8) Acupuncture vs. waiting list -4.3 (95%CI: -6.5, -2.0)
Cherkin 2001^29^ | Acupuncture (94) | Self care (90) | LBP, NS, Chronic | Number of pain medication fills- 1 year | 4.4 (8.9) | 4.0 (8.6) | NS
Kennedy, 2008^202^ | Acupuncture (24) | Placebo (24) | LBP, NS, Acute | Mean (SD) tablets/day at end of tx | 1.0 (0.3) | 4.2 (0.6) | S
Thomas 2006^111^ | Acupuncture (160) | Usual care (81) | LBP, N-S, Mixed | Pts using any medication in past 4 weeks- 2 years | 40% | 59% | S (-19, 95% CI:-35.0, -3.0)
Grant 1999^53^ | Acupuncture (32) | TENS (28) | LBP, N-S, Chronic (elderly | Median (IQ range) tablets consumed in last week-immediate post tx (B); 3 months (C) | B) 15 (5-37) C) 14 (0-38) | B) 28 (7-42) C) 24 (2-42) | S
Sator- Katzenschlager 2004^143^ | Acupuncture (electrical/auricular) (31) | Acupuncture (manual/auricular) (30) | LBP, N-S, Chronic | Consumption of rescue medication (Tramadol), number of tablets used- | 6 | 150 | S
Spinal manipulation
Childs 2004^31^ | Spinal manipulation + exercise (70) | Exercise alone (61) | LBP, NS, Mixed | % of pts taking any medication in past week – 6 mo fu | 9.6% | 25% | S
Hurwitz 2006^66^ | Spinal manipulation (169) | Medical care (170) | LBP, N-S, Mixed | % of pts using prescription pain medication- 6 months (D), 1 year (E1), 18 months (E2) | D) 24% E1) 20% E2) 19% | D) 32% E1) 29% E2) 27% | NS (also pts in Spinal manipulation were more likely to use over the counter pain medication at D than pts in medical care, but not at E1-2, 56% vs.49%, respectively)
Meade 1991^95^ | Spinal manipulation (treated by chiropractor) (384) | Hospital outpatient management (357) | LBP, N-S, Unknown/Mixed | Pts using analgesics and anti inflammatory drugs- 6 months (D); 1 year (E1); 2 years (E2) | D) 33% E1) 30% E2) 30% | D) 35% E1) 29% E2) 36% | -1.8 (95% CI: -9.3, 5.7) 0.7 (95% CI: - 7.6, 9.0) -6.0 (95% CI: -19.1, 7.1)
Santilli 2006^391^ | Spinal manipulation (53) | Placebo manipulation (simulated Spinal manipulation) (49) | LBP and Sciatica, Specific, Acute/subacute | Number of days onanti inflammatory drugs (NSAIDs) | 1.8 (2.9) | 3.7 (7.1) | NS
Santilli 2006^391^ | Spinal manipulation (53) | Placebo manipulation (simulated Spinal manipulation) (49) | LBP and Sciatica, Specific, Acute | Number of drug prescriptions- | 2.6 (4.0) | 4.6 (8.9) | NS
Niemistö 2003^385^ | Spinal manipulation (102) | Physician consultation (102) | LBP, N-S, chronic | Pts using analgesics for LBP- 1 year | 23% | 26% | NS
Nordaren, WU 1992^346^ | Spinal mobilization (18) | Placebo (massage) (21) | LBP, and Sciatica, Specific Acute/subacute | Number of analgesic pills (median, range) | 0(0-132) | 3.5 (0.5) | S (p< 0.05)
Massage
Cherkin 2001^29^ | Massage (94) | Self care (90) | LBP, NS, Chronic | Number of pain medication fills- 1 year | 2.5 (3.6) | 4.0 (8.6) | S
Poole 2007^369^ | Massage (77) | Relaxation; (82) | LBP, NS, Chronic | Pts using prescribed medication for LBP- 6 months | 43.1% | 52.6%; 55.8% | NR
Poole 2007^369^ | Massage (77) | Relaxation; (82) | LBP, N-S, Chronic | Pts using over the counter medication for LBP- 6 months | 18.5% | 15.8%; 18.6% | NS

Data are given as mean(SD) when not indicated

End point= denotes the last follow up in which the data was reported

NS= not significant; N-S=nonspecific; pt/s= patient/s; tx=treatment/intervention; LBP= low back pain; TENS= transcutaneous electrical stimulation; B=immediately post treatment; C= short term follow up (up to 3 months post treatment); D=intermediate follow up (up to 6 months post treatment); E=long term follow up (over 6 months post treatment)

Table 28 Utility of conventional medicine for low back pain: Use of conventional treatments

Author, Year (ID) | Intervention | Control | Region, Cause, duration of Pain | Healthcare Utilization- end point | Results CAM | Results Control | CAM vs. Control
Acupuncture
Cherkin 2001^29^ | Acupuncture (94) | Self care (90) Massage (78) | LBP, N-S, Chronic | Number of provider visits- 1 year | 1.9 (3.7) | 1.5 (4.0) 1.0 (2.1) | NS
Cherkin 2001^29^ | Acupuncture (94) | Self care (90) Massage (78) | LBP, N-S, Chronic | Number of imaging studies- 1 year | 0.2 (0.4) | 0.1 (0.4) 0.1 (0.4) | NS
Thomas 2008^112^ | Acupuncture (123) | Usual care (59) | LBP, N-S, Chronic | Mean number of healthcare visits: a-GP b-outpatient c- NHS (National Health Services) d- private - 2 years | a- 3.78 (3.36) b- 0.50 (1.62) c- 8.79 (5.30) d- 0.98 (4.68 | a- 4.25 (4.74) b- 0.41 (1.95) c- 9.59 (5.60) d- 0.90 (3.65) | NS
Spinal manipulation
Cherkin 2004^31^ | Spinal manipulation + exercise (70) | Exercise alone (61) | LBP, N-S, Mixed | % of pts seeking tx for LBP- 6 mo fu | 11.5% | 42.5% | S
Meade 1991^95^ | Spinal manipulation (treated by chiropractor) (384) | Hospital outpatient management (357) | LBP, N-S, | Pts seeking any further tx- between 1 and 2 years | 36% | 41% | -4.9 (95% CI: -18.5, 8.7)
Niemistö385 | Spinal manipulation (102) | Physician consultation (102) | LBP, N-S, Chronic | Number of visits to physicians- 1 year | 2.1 (2.6) | 2.4 (3.3) | NS
Niemistö385 | Spinal manipulation (102) | Physician consultation (102) | LBP, N-S, chronic | Number of visits to physiotherapy or other therapists- 1 year | 7.6 (7.7) | 6.0 (7.3) | NS
Spinal mobilization
Hemmila, HM 2002^342^ | Spinal mobilization (bone setting)(44) | Physiotherapy (34) | LBP, N-S Chronic | Mean change from baseline in number of visits to health centers for back pain | 0.1 | 0.5 | S (only in Physiotherapy group compared to baseline)
Hemmila, HM 2002^342^ | Spinal mobilization (bone setting)(44) | Exercise (35) | LBP, N-S Chronic | Mean change from baseline in number of visits to health centers for back pain | 0.1 | 0.1 | NS
Massage
Cherkin 2001^29^ | Massage (94) | Self care (90) | LBP, N-S, Chronic | Number of imaging studies- 1 year | 0.1 (0.4) | 0.1 (0.4) | NS
Cherkin 2001^29^ | Massage (94) | Self care (90) | LBP, N-S, Chronic | Number of provider visits- 1 year | 1.0 (2.1) | 1.5 (4.0) | NS
Poole 2007^369^ | Massage (77) | Relaxation; (82) Usual care (131) | LBP, N-S, Chronic | Pts using usual care (including medication)- 6 months | 47.0% | 36.8%; 30.2% | No statistical results reported. The data for pts using treatments other than medication could not be teased out appropriately

Data are given as mean(SD) when not indicated

End point= denotes the last follow up in which the data was reported

NS= not significant; N-S=nonspecific; pt/s= patient/s; tx=treatment/intervention; LBP= low back pain; TENS= transcutaneous electrical stimulation; B=immediately post treatment; C= short term follow up (up to 3 months post treatment); D=intermediate follow up (up to 6 months post treatment); E=long term follow up (over 6 months post treatment)

Table 29 Utility of conventional medicine for low back pain: Work absenteeism

Author, Year (ID) | Intervention (number of subjects) | Control (number of subjects) | Region, Cause, duration of Pain | Healthcare Utilization- end point | Results CAM | Results Control | CAM vs. Control
Acupuncture
Kennedy, 2008^202^ | Acupuncture (24) | Placebo (24) | LBP, NS, Acute | Days off work- at end of tx | 13.9 (5.3) | 10.9 (4.1) | NS
Sator- Katzenschlager 2004^143^ | Acupuncture (electrical/auricular) (31) | Acupuncture (manual/auricular) (30) | LBP, NS, Chronic | Time to return to full time work | No numerical data reported | No numerical data reported | Pts in electrical auricular acupuncture returned to work earlier than pts in manual acupuncture
Spinal manipulation
Childs 2004^31^ | Spinal manipulation + exercise (70) | Exercise alone (61) | LBP, NS, Mixed | % of pts with missed any time work in past 6 wks- 6 mo fu | 41.2% | 38.3% | NS
Niemistö385 | Spinal manipulation (102) | Physician consultation (102) | LBP, N-S, chronic | Days absence of work- 1 year | 13.9 (26.6) | 18.5 (38.8) | NS
Nordgren, WU 1992^346^ | Spinal mobilization (18) | Placebo (massage) (21) | LBP, and Sciatica, Specific Acute/subacute | Median duration of sick leaves during the follow-up period | 7, (0-35) | 14 (0-26) | S (p < 0.05)
Hemmila, HM 2002^342^ | Spinal mobilization (bone setting)(44) | Physiotherapy (34) | LBP, N-S Chronic | Mean change in sick leave days for back pain-comparison between year before and year after the intervention | 0.8 | 2.1 | NS
Hemmila, HM 2002^342^ | Spinal mobilization (bone setting)(44) | Exercise (35) | LBP, N-S Chronic | Mean change in sick leave days for back pain-comparison between year before and year after the intervention | 0.8 | -1.0 | NS
Hemmila, HM 2002^342^ | Spinal mobilization (bone setting)(44) | Physiotherapy (34) | LBP, N-S Chronic | % of patients on sick leave for back pain in the year after therapy | 16% | 9% | NS
Hemmila, HM 2002^342^ | Spinal mobilization (bone setting)(44) | Exercise (35) | LBP, N-S Chronic | % of patients on sick leave for back pain in the year after therapy | 16% | 17% | NS

Data are given as mean(SD) when not indicated

End point= denotes the last follow up in which the data was reported

NS= not significant; N-S=non-specific; pt/s= patient/s; tx=treatment/intervention; LBP= low back pain; TENS= transcutaneous electrical stimulation; B=immediately post treatment; C= short term follow up (up to 3 months post treatment); D=intermediate follow up (up to 6 months post treatment); E=long term follow up (over 6 months post treatment)

Acupuncture. In the first trial,202 there was no statistically significant difference between subjects in acupuncture and placebo groups in the post-treatment number of days off work. The mean (or median) number of pain medication pills per unit of time (day of week) was significantly lower in subjects who received acupuncture compared to those who received placebo (mean number of pills per day: 1.0 ± 0.3 versus 4.2 ± 0.6)202 or TENS (median number of pills per week: 15 versus 28).53 Subjects receiving acupuncture had significantly lower number of days using analgesics compared to subjects receiving no treatment or placebo.22

The time to return to full time work and number of pills consumed was significantly shorter/lower for subjects receiving electro-acupuncture compared to subjects receiving manual acupuncture (no numerical data were given).

Subjects receiving acupuncture did not significantly differ from subjects receiving self-care in the number of medication fills (4.4 ± 8.9 versus4.0 ± 8.6), provider visits, or imaging tests per year.29 Similar results were obtained in another study that compared acupuncture to usual care for chronic nonspecific patients in a 2 year study. One trial,111 reported numerically lower proportions of any medication users amongst subjects in the acupuncture versus usual care groups (40.0 percent versus 59.0 percent).

Manipulation. Most studies reporting the data on days off work, medication use, and health care utilization indicated nonsignificant differences between the groups of spinal manipulation and exercise (days off work),31 physician consultation (days off work, healthcare utilization),385 medical care (pain medication use: proportion of users or number of pills),66 or placebo (pain medication use: proportion of users or number of pills).39

Mobilization. In one trial in subjects with low back pain and sciatica due to sacroiliac joint dysfunction, the median number of analgesic pills taken was significantly higher in the placebo group (median: 3.5, range: 0-54) compared to mobilization group (median: 0, range: 0-132).346 The median duration of sick leave (in days) was also significantly greater in the placebo (median: 14, range: 0-26) versus mobilization group (median: 7, range: 0-35).346

In another trial including patients with chronic nonspecific low back pain, the number of patients on sick leave decreased in three groups of patients randomized to bone setting, physiotherapy and exercise. There were no significant differences in proportion of patients on sick leave in the year before the intervention compared to the year after the intervention between the three groups. In this study, the average number of visits to health centers for back pain was reduced in all three groups, but was only significant in physiotherapy group.342 (Table 26)

Massage. There were no statistically significant differences in pain medication use (e.g., proportion of patients using medications) and number of provider visits between subjects who received massage versus relaxation or self-care at end of treatment.29,369

### Neck Pain

The comparative data on days off work, medication use, and health care utilization reported for 12 trials of neck pain are presented in Tables 30-31.^126,127,235,259,263,266,267,271,320,352,353,383^

Table 30 Utility of conventional medicine for neck pain: Use of medication

Author, Year (ID) | Intervention | Control | Cause, duration of Pain | Medication intake- end point | Results CAM | Results Control | CAM vs. Control
Acupuncture
Ilbuldu 2004^263^ | Acupuncture (dry needling) (20) | 1- Laser tx (20) 2- Placebo laser (20) | NP; Myofascial Pain; Mixed | Mean analgesic use- 4 weeks (B); 6 months (D) | B) 3.6 (4.4) D) 2.5 (2.7) | B) 1- 0.8 (1.3); 2- 2.1 (3.4) D) 1- 1.1 (3.4); 2- 2.5 (3.5) | B) S D) NS
Petrie 1986^266^ | Acupuncture (13) | Placebo TENS (12) | NP- N-S, Chronic | Mean daily pill count- 4 weeks (B); 3 months (C) | B) 2.7 (2.5) C) 2.4 (2.6) | B) 1.2 (1.1) C) 0.8 (0.5) | NS
Vas 2006^259^ | Acupuncture (61) | Placebo TENS (62) | NP; N-S; chronic | Pts (%) taking some rescue medication- one week post tx (C), | 29.5% | 98.3% | 4.0 (95% CI: 2.3, 7.0)
Vas 2006^259^ | Acupuncture (61) | Placebo TENS (62) | NP; N-S; chronic | Pts (%) using other medications (tetrazepam)- one week post tx (C) | 8 (29.6%) | 19 (67.9%) | NR
Salter 2006^267^ | Acupuncture + GP care (10) | GP care (14) | NP- N-S, Chronic | Number of pts using medication- 3 months | 11.1% | 41.7% | NS
Venancio 2008^126^ | Acupuncture (15) | Lidocaine injection; Lidocaine + corticoid (30) | Headache, N-S; Chronic | Number of analgesics (ibuprofen tablets) ingested- 3 months | 32.9 (61.7) | 32.3 (45.2); 17.8 (25.8) | NS
Venancio 2009^127^ | Acupuncture (15) | Botulinum toxin [not sure, possibly same as REFID 19: (30)] - SG | Headache, N-S; Chronic | Number of analgesics (ibuprofen tablets) ingested- 3 months | 32.9 (61.7) | 15.5 (21.9) | NS
White 2000^271^ | Acupuncture (ES) at local points (68) | Acupuncture (ES) at local points (68) | NP- Specific; Chronic | Mean (SD) % decrease in average oral analgesic medication- 3 months | 37% (18%) | 9% (13%) | S
White 2000^271^(Cross over) | Acupuncture (ES) at local points (68) | Acupuncture (no ES) at local points (68) | NP- Specific; Chronic | Mean (SD) % decrease in average oral analgesic medication- 3 months | 37% (18%) | 6% (15%) | S
Spinal mobilization
Hemmila 2005^352^ | Mobilization (22) | No tx (intervention was neither offered nor denied) (20) | NP- N-S; Mixed/Unknown | The mean annual number of doses- 1 year | 63 (146) | 188 (332) | NS
Zaproudina 2007^353^ | Mobilization (35) | Physiotherapy (34) | NP- N-S, Chronic | Decrease in use of painkillers (%)- 1 year | 67.0% | 50.0% | NR
Massage
Zaproudina 2007^353^ | Massage (35) | Physiotherapy (34) | NP- N-S, Chronic | Decrease in use of painkillers (%)- 1 year | 56.2% | 50.0% | NS
Cen, 2009^383^ | Massage (32) | Self care book (32) | NP- N-S, Chronic | Increase in use of medication-6 months | 0% (no change) | 14% | S

Data are given as mean(SD) when not indicated

End point= denotes the last follow up in which the data was reported

NS= not significant; N-S=nonspecific; pt/s= patient/s; tx=treatment/intervention; LBP= low back pain; TENS= transcutaneous electrical stimulation; B=immediately post treatment; C= short term follow up (up to 3 months post treatment); D=intermediate follow up (up to 6 months post treatment); E=long term follow up (over 6 months post treatment)

Table 31 Utility of conventional medicine for neck pain: Work absenteeism

Author, Year (ID) | Intervention | Control | Cause, duration of Pain | Work outcome- end point | Results CAM | Results Control | CAM vs. Control
Spinal mobilization
Hemmila 2005^352^ | Mobilization (22) | No treatment (intervention was neither offered nor denied) (20) | NP- N-S; Mixed/Unknown | Mean sick leave days prescribed due to NP- 1 year | 4.5 (20.0) | 16.9 (53.0) | NR
Hemmila 2005^352^ | Mobilization (22) | No treatment (intervention was neither offered nor denied) (20) | NP- N-S; Mixed/Unknown | Number of pts prescribed sick leave- 1 year | 3 (13.6%) | 5 (25.0%) | NR
Zaproudina 2007^353^ | Mobilization (35) | Physiotherapy (34) | NP- N-S, Chronic | Number of sick leave days per person- 1 year | 0.61 | 2.6 | S
Kongste 2007^359^ | Mobilization (149) | Neck collar; (156) Act as usual (153) | NP; Specific (whiplash); Acute | Pts with affected work ability, % (95%CI)- 1 year | 22% (95% CI: 15, 30) | 28% (95%CI: 20, 36) 25% 95%CI: 17, 33) | NS
Massage
Zaproudina 2007^353^ | Massage (35) | Physiotherapy (34) | NP- N-S, Chronic | Number of sick leave days | 3.9 | 2.6 | NR

Data are given as mean(SD) when not indicated End point= denotes the last follow up in which the data was reported

NS= not significant; N-S=nonspecific; pt/s= patient/s; tx=treatment/intervention; acu=acupuncture; SM=spinal manipulation; LBP= low back pain; TENS= transcutaneous electrical stimulation; B=immediately post treatment; C= short term follow up (up to 3 months post treatment); D=intermediate follow up (up to 6 months post treatment); E=long term follow up (over 6 months post treatment)

Acupuncture. The number of analgesics consumed by subjects receiving acupuncture did not significantly differ from that consumed by subjects receiving Botulinum toxin127 or Lidocaine injection.126 The proportion of patients not taking rescue medication was significantly greater in the acupuncture versus placebo group (RR = 4.0, 95 percent CI: 2.3, 7.0).259 In another trial,271 the mean percent decrease in analgesic use was significantly greater in the local acupuncture versus remote acupuncture group (37.0 percent versus 9.0 percent).

Manipulation. No relevant trials were identified.

Mobilization. In two studies, analgesic medication use (i.e., percent decrease in annual use, mean annual number of doses) and the mean number of sick leave days were numerically better (no statistical test results reported) in the mobilization group versus no treatment352 or physiotherapy (massage, stretching, and exercise).35

Massage. In the massage groups of two trials,353,383 the use of pain medication was significantly lower compared to the self-care book (mean increase: 0 percent versus 14.0 percent respectively)383 but not significantly different compared to physiotherapy group (mean decrease: 56.2 percent versus 50.0 percent, respectively).353

### Publication Bias

Visual inspection of the funnel plot (Figure 50) for the acupuncture trials comparing immediate mean post-treatment VAS scores between acupuncture and placebo treatment groups suggested some degree of asymmetry. Specifically, there was a relative lack of trials with negative results (i.e., fewer trials in areas of statistical nonsignificance), indicating a potential for publication bias. The Egger’s regression-based analysis16 yielded a statistically significant result (p = 0.03).

Figure 50 Funnel plot of trials comparing VAS score (acupuncture versus placebo)

Figure 50 depicts Visual inspection of a funnel plot for the acupuncture trials comparing immediate mean post-treatment VAS scores between acupuncture and placebo treatment groups. It suggests some degree of asymmetry. Specifically, there was a relative lack of trials with negative results (i.e., fewer trials in areas of statistical nonsignificance), indicating a potential for publication bias.

## KQ2 What are the Contraindications and Safety Profile of the Three Most Prevalent CAM Therapies for Back Pain in Adults Compared to That for Other CAM Therapies, Conventional Therapies, Placebo or no Treatment? Does the Safety Profile of These Therapies Change Across Subgroups of Patients With Comorbidities?

### Harms of CAM in RCTs

#### 1 Acupuncture for Treatment of Low Back Pain

Any information on harms was reported for 25 trials.22,24,29,37,49,53,110,121,136,138,139,143,156,162,197,198,198,200,207,209,216,220,224,226,228 Most reported events that were of moderate and transient nature. Specific adverse events reported by subjects who received acupuncture were soreness/pain at the site of needling,22,24,29,49,110,121,136,156,162,198,198,207,224,226,228 bruising,226 light headedness,226 minor bleeding,22,24,121,136,138,139,156 dizziness,53,136 influenza,53 problem with circulation,198 or headache.136 In one trial,143 reportedly no needle-induced adverse events had occurred.

In two trials, the proportion of subjects with any adverse events did not differ between acupuncture and placebo groups.22,37 For example, in one of these trials,22 10.7 percent (15/140) and 17.1 percent (12/70) of subjects reported any adverse events for the acupuncture and the placebo group, respectively (p = 0.20). One trial228 reported 3.8 percent (6/147) of the subjects in the acupuncture having an adverse event versus none in the placebo group (p = 0.04). In another trial,207 one patient in acupuncture group (n=13) reported deterioration of symptoms and withdrew from the trial. There were seven patients in the acupuncture (n=32) and four patients in the placebo (minimal needling) group (n=28), respectively who reported bleeding.156

The proportion of subjects with at least one adverse event was similar in acupuncture and usual care (or conventional treatment) groups.37,49,220,226 Subjects in usual care groups had epigastric pain,139,220,226 nausea,139 poor appetite,139 or headache.136,139,226 In one of these trials,220 the medication group reported higher proportion of gastroenteric adverse events compared with the acupuncture group (15/29 versus 0/28, p < 0.01).

In three trials,53,121,216 the incidence of adverse events in acupuncture (or electro-acupuncture) and TENS was numerically similar. In one of these trials,53 there were 16.6 percent (5/30) and 14.8 percent (4/27) of the subjects who had an adverse event. In the other trial,216 one patient dropped out due to deterioration of symptoms after receiving the combination of acupuncture and TENS.

In one trial,29 11 percent (10/94) of patients in the acupuncture group and 13 percent (10/78) in the massage group reported “significant discomfort or pain” during or shortly after treatment. In another trial,200 comparing acupuncture plus exercise to exercise alone, one patient in the combination group (n=26), developed stroke. Three patients in one trial did not tolerate pain during tapping in the dermal needling group (n=88) and were excluded without receiving the treatment.162 One patient experienced itching with electrode (acupuncture with electric stimulation group; n=31) and one patient had dullness after treatment with TENS (n=33).209

In one trial,136 the proportions of subjects with an adverse event in the high-frequency acupuncture (five times per week) and the low-frequency acupuncture (two times per week) groups were 73.3 percent (11/15) and 46.6 percent (7/15), respectively (p-value not reported).

In four trials, reportedly no serious adverse events occurred in acupuncture versus massage,29 usual care110 ‘no treatment,’24,29 or placebo (sham-acupuncture) group.197 For one trial,37 after 6 months of followup, 40 and 12 serious adverse events were reported for the acupuncture (n=387) and the usual care group (n=388), respectively. Similarly, another trial,22 reported 9.3 percent (13/140) and 5.7 percent of (4/70) of the subjects had serious adverse events in the acupuncture and placebo groups, respectively.

#### 2 Acupuncture for Treatment of Neck Pain

Only 13 trials reported any information on adverse events.45,46,51,77,80,128,131,235,256,257,259,262,272 The reporting of adverse events in these trials was generally poor (i.e., inconsistent, not enough detail, not well defined, no numerical or statistical data).

For example, in two trials45,262 comparing acupuncture to Lidocaine injection, no severe adverse events were observed262 and one patient treated with acupuncture (n=18) withdrew from the trial due to cholecystectomy.45 The proportions of patients with soreness in the acupuncture and Lidocaine injection groups were 50.0 percent (9/18) and 38.1 percent (8/18), respectively (p = 0.74).45 In the same trial, none of the subjects who received acupuncture developed dizziness or haemorrhage, whereas there were two subjects each with either dizziness or haemorrhage in the Lidocaine injection group (0 percent versus 4.8 percent).

In seven trials, the proportions of patients who withdrew or those reporting adverse events were similar in acupuncture (range: 6.0 percent-33.0 percent) versus placebo (TNS) groups (range: 0 percent-21.0 percent).77,80,128,256,257,259,272 The patients who received acupuncture reported the following events: needle reaction, mild headache, euphoria, enhanced vision, dizziness, mild hypotonia, sweating, swelling of the hand, bruising, and ulcer of the ear,77,80,128,259 whereas patients in the placebo groups reported cephalea,259 aggravation of symptoms,128,256,259 tiredness, nausea, tingling in the thumb, or uncomfortable cold feeling from the electrodes.128 No serious adverse events were reportedly noted.77,80

In one trial,51 no adverse events were reported for patients receiving acupuncture (n=34) or manipulation (n=35); In total, about 6.1 percent (4/40) patients who were treated with medications (e.g., 200-400 mg/d Celebrex, 12.5-25.0 mg/d Vioxx) had indigestion, abdominal pain, or skin rash. In another trial,131 8.3 percent (n=1005) of the patients treated with acupuncture (both randomized and nonrandomized: n=12148) developed adverse events (minor local bleeding or hematoma, needing pain, or vegetative symptoms).

No post-needling soreness, hypotension, or hematoma was observed in two other trials comparing acupuncture alone to the combination of acupuncture either with electro-stimulation235 or paraspinal needling.46

#### 3 Manipulation for Treatment of Low Back Pain

Any information on harms was reported for only four trials.276,288,290,296 The reported adverse events were mostly moderate in severity and of transient nature. Most commonly reported specific event in subjects randomized to manipulation was increased pain or soreness.276,290,296 In the first trial,276 there were four and three subjects with worsening of LBP in the manipulation (n=35) and exercise (n=37) groups, respectively. In the second trial,290 there were six and four subjects with an adverse event in the manipulation (n=47) and myofascial therapy (n=50) groups, respectively. One subject in the myofascial therapy group developed constant tinnitus.290 In one trial,288 no adverse events were registered except for one subject (group identity not reported) who had constipation after consuming 24 Codeine Phosphate capsules in the first 4 days. Another trial296 reported the absence of serious adverse events in subjects with subacute or chronic LBP randomized to manipulation (n=191) or standard care (Paracetamol, Acetaminophen, NSAIDs, or muscle relaxants; n=49). The number of adverse events in two manipulation groups (high-velocity low-amplitude and low-velocity variable-amplitude; n=191) was 16 (15 events of low back soreness/pain) compared to four adverse events (rash due to Celebrex, headache, leg cramps/pain across chest, slurred speech) in the standard treatment group (n=49).

#### 4 Manipulation + Mobilization for Treatment of Low Back Pain

Only three trials reported any harms related data.39,56,66 In one trial,39 reportedly no adverse events had occurred. In another trial,66 no treatment-related adverse events requiring institutional review board notification had occurred. One trial reported the absence of serious adverse events in subjects receiving manipulation (n=59).56 In the same trial, 22 subjects (11 subjects in the medication - NSAIDs, analgesics group and 11 subjects in placebo group) reported dizziness, gastrointestinal disturbances, and heart palpitations.56 One patient in the medication group (n=60) had a suspected hypersensitivity and withdrew from the trial.

#### 5 Flexion Distraction for Treatment of Low Back Pain

Only one trial305 reported any information on harms. In this study, reportedly no adverse event had occurred during the study period.

#### 6 Manipulation for Treatment of Neck Pain

Only six trials reported any information on adverse events.51,65,306,320,323,329 The reporting of adverse events in the majority of these trials was generally poor (i.e., inconsistent, not enough detail, not well defined, no numerical or statistical data). Results for one trial are presented in the Acupuncture section, Harms sub-section.51,52

In one trial of 280 patients comparing manipulation to mobilization,65,69 after 2 weeks of treatment, patients randomized to manipulation (n=171) were at statistically nonsignificantly increased risk for having any adverse event (adjusted OR = 1.44, 95 percent CI: 0.85, 2.43) compared to patients randomized to mobilization (n=165). Most frequently reported events were neck soreness/stiffness (27.7 percent versus 22.3 percent), radiating pain (6.4 percent versus 5.8 percent), tiredness (12.1 percent versus7.9 percent), headache (15.6 percent versus 15.8 percent), and dizziness (4.3 percent versus 2.2 percent). Another trial,329 reported proportions of patients with at least one adverse event in the manipulation plus Diazepam group and the Diazepam group alone were 9.5 percent (2/21) and 11.1 percent (2/18; superficial phlebitis), respectively. There were reportedly no serious adverse events in one trial306 in patients randomized to the combination of manipulation and mobilization with (n=30) or without thrust (n=30). There were nine and ten patients reporting mild-to-moderate severity adverse events in the nonthrust and thrust groups, respectively (p = 0.67).

In one trial,323 two subjects, one in the manipulation (n=3) and the other in the manipulation combination group (n=3) experienced transient but severe neck pain/stiffness.

#### 7 Manipulation + Mobilization for Treatment of Neck Pain

In one trial,81,83 although there were no important adverse events, 6.7 percent (not specified the number of subjects or a treatment group - manipulation plus exercise: n=49, manipulation alone: n=51) of the subjects reported provoked headaches as a result of the intervention.

#### 8 Mobilization for Treatment of Low Back Pain

None of the reviewed trials provided any information on the absence or presence of harms reported by subjects.

#### 9 Mobilization for Treatment of Neck Pain

Any information on adverse events was reported for two studies.320,357 In the first study, none of the patients reported any adverse events.357 In the other trial,320 posterior-anterior unilateral pressure (PAUP), anterior-posterior unilateral pressure (APUP), transverse oscillatory pressure (TOP), and cervical oscillatory rotation (COR) techniques did not worsen the patients’ condition. The relapse rates in the TOP and COR treatment groups after 3 months were 8.0 percent (2/24) and 12.0 percent (3/24), respectively.

#### 10 Mobilization for Treatment of Thoracic Pain

None of the reviewed trials provided any information on the absence or presence of harms reported by subjects.

#### 11 Massage for Treatment of Low Back Pain

Any information on harms was reported only for four trials.90,366-368 For two trials,366,368 it was explicitly stated that no adverse events had occurred during the treatment period. In one trial,90 one subject reported worsening of back pain in the massage group (n=75) as opposed to no adverse events reported for the group of exercise (n=72) or Alexander technique lessons (n=73). In another trial,367 five to 10 subjects from each group (Thai-massage: n=90 versus Swedish massage: n=90) reported soreness of transient nature which disappeared in 5-10 minutes. There were five additional subjects in the Swedish massage group (n=90) who reported allergic reaction (rashes and pimples) to the massage oil.367

#### 12 Massage for Treatment of Neck Pain

Only two studies reported any information on adverse events.77,383 In one trial,77 the proportion of patients with adverse events in massage group was numerically lower 7.0 percent (4/57) compared to acupuncture 33.0 percent (17/51) or placebo-laser 21.0 percent (12/57). No serious adverse events were observed in this trial. In the other trial,383 nine patients randomized to massage (n=32) had mild adverse events (discomfort or pain: n = 5, increased soreness post-treatment: n = 3, and nausea: n = 1).

### Harms Reported in Nonrandomized Controlled Studies

This review identified five nonrandomized studies and one experimental controlled trial, 224 The nonrandomized studies included two cohorts,392,393 and three case-control studies6,394,395 that reported on the incidence of harms in subjects receiving CAM therapies.

#### Acupuncture for Treatment of Low Back Pain

Although one study,224 was a trial that compared subjects with acute nonspecific LBP randomly assigned to usual care or choice of CAM care (acupuncture, massage, and chiropractic therapy), the occurrence of harms was reported only for the three groups of subjects who chose to receive acupuncture, chiropractic therapy, or massage within the choice of CAM care group (n = 300). The post-treatment rates of minor (clinically in-significant) discomfort or soreness in the acupuncture, chiropractic therapy, and massage groups were 5.0 percent (3/58), 8.0 percent (6/76), and 7.0 percent (10/152), respectively. No further details of harms were described.

#### Manipulation and Mobilization for Treatment of Low Back Pain

In a retrospective cohort study,392 the rates complications were compared between two groups of subjects with nonspecific LBP of unknown duration who had received either mobilization plus manipulation (n=75) or no therapy (n=75). Findings showed no differences in rates of complications between the two groups. No further description of adverse events was provided in this study. The authors also reported that subjects who received chiropractic therapy had a longer mean length of hospital stay (4.52, 95 percent CI: 3.78, 5.36) and lower cost of treatment compared to subjects who did not receive such therapy (3.40, 95 percent CI: 2.87, 4.03), the between-group difference being statistically significant (p < 0.01).

In a small prospective cohort study of 68 chronic LBP patients,393 treatment with medication-assisted manipulation or spinal manipulation alone for at least 4 – 6 weeks resulted in no complications. In this study spinal manipulation had been delivered by two chiropractors. In addition to the intervention treatment, participants received advice for exercise.

#### Spinal Manipulation for Treatment of Neck Pain

In a nested case-control study,394 patients under the age of 60 years with cervical arterial dissection and ischemic stroke or TIA were followed-up (1995-2000) matched to controls (by sex and within age strata). This study showed that SMT was independently associated with a greater risk of vertebral arterial dissection, even after controlling for neck pain. In this study, patients with arterial dissection (n = 51) compared to controls (n = 100) were more likely to have had SMT within 30 days (14.0 percent versus 3.0 percent, p = 0.032). In multivariate analysis, SMT within 30 days was associated with a significantly greater risk of vertebral artery dissection (OR = 6.6, 95 percent CI: 1.4 to 30.0).

In another case-control study conducted in Canada and involving 582 cases each matched with four age and sex controls, cases were five times more likely than controls to have visited a chiropractor in the week before a vertebro-basilar accident (OR= 5.03, 95 percent CI: 1.3, 43.8). These patients were also five times more likely to have had ≥ three visits to a chiropractic care in the month before the vertebro-basilar accident (OR= 4.98, 95 percent CI: 1.3, 18.6). These associations were observed only for patients aged 45 years or younger.6

In a recently published case control study,395 818 cases with and 3164 matched controls without vertebro-basilar artery (VBA) stroke were compared with respect to having received chiropractic treatment.

A chiropractic visit in the month before the index date was associated with an increased risk of VBA stroke in those under 45 years of age (OR=3.13, 95 percent CI: 1.48, 6.63). Similarly, increased risk was found for patients visiting a primary care physician in the month before the index date for patients under 45 years of age (OR= 3.57, 95 percent CI: 2.17, 5.86) and patients over 45 years of age (OR= 2.67, 95 percent CI: 2.25, 3.17).