# Methods

## Key Questions

The current systematic review is supported by (NCCAM) and (AHRQ) in order to better understand the status of research that has been done in treatment of back pain (cervical, thoracic, lumbar regions) with some of the most prevalent CAM interventions as identified by a recent review (CAM I)

1. What is the efficacy, effectiveness and cost-effectiveness of the most prevalent types of practitioner-based manual CAM therapies (e.g., spinal manipulation, spinal mobilization, massage; acupuncture) compared to other CAM therapies, conventional therapies, placebo, no treatment, or wait list in improving outcomes (e.g., QoL, Pain, Function, progression of acute to chronic/ or disabling BP) in patients with nonspecific and certain specific (e.g. disc herniation, spinal stenosis, facet joint syndrome, whiplash) types of back and neck pain.
  a. For any of the CAM therapies found to be effective for BP, what factors influence success of treatments?
    i. Patient-specific factors:
    ii. Socio-demographics (e.g., age, gender, race, education, income)
    iii. Comorbidities
  b. Severity, specific causes (as identified in Q1), and duration of BP
    i. Treatment-specific factors (e.g., dose, frequency, duration)
    ii. Treatment provider-specific factors (e.g., training, specialization, experience)
  c. Does the use of any of the three most prevalent types of CAM for BP in adults result in a decreased or increased utilization of conventional management (diagnostic tests, number of visits & dose of medications, procedures)?
2. What are the contraindications and safety profile of the three most prevalent CAM therapies for BP in adults compared to that for other CAM therapies, conventional therapies, placebo or no treatment? Does the safety profile of these therapies change across subgroups of patients with co morbidities?

For a schematic view of the key questions that incorporates the relevant clinical context, please refer to Figure 1.

## Analytical Framework

Figure 1 Analytical framework

Figure 1 depicts the analytical framework. The first column on the left hand side is headed “Population.” Under that is an oval shaped circle with the following text inside: Adult Patients with Back Pain (Low back, Neck 7 Thoracic); Duration of pain: acute/subacute, chronic, mixed/unknown; Classified as: 1 - Non-specific, 2 - Specific cause (disc herniation; degenerative disc disease, myofacial pain syndrome, etc.) A heavy arrow points to a vertical line connecting the top (first) and bottom (third) boxes in the next column, which is headed Choice of Treatment. Under that is a box in which is written Conventional care (general practitioner care, medication; physiotherapy, etc.). Under that box is another box containing the words, No treatment/rest/moderation of activities. Under that is a third box containing the words CAM treatments (acupuncture, spinal manipulation of mobilization; soft tissue massage). All three of the above boxes in this column have horizontal lines coming out to the right to a vertical line. A dollar sign is superimposed over the top and bottom horizontal lines. The vertical lines points to an oval circle at the bottom that contains the words Direct costs. An arrow connects that box up and to the right to a box on the bottom of the third column that contains the words Cost effectiveness: Cost with respect to clinical outcomes: and a dollar sign to the left. The third column is headed Outcomes. Individual boxes are lined up under that heading with the words Pain, Loss of function, Quality of life, Work absenteeism, Conventional care use, Any adverse events, Range of motion, Muscle strength, Physiological measures, and the bottom box mentioned above. Horizontal lines with dollar signs on them come out from the Loss of function and Work absenteeism boxes to a longer vertical line that points down to an oval box, Indirect costs. On the right hand edge are three vertical boxes, the first containing the words KQ1: Direct (clinical) outcomes, the next, KQ2: harms, and the last, KQ1: Indirect outcomes. At the bottom, between the KQ1: Indirect outcomes box and the Cost effectiveness: Cost with respect to clinical outcomes box is the oval box, Indirect costs, with an arrow pointing to the Cost effectiveness box. Under the first column is a box, Diagnosis, and under the rest of the columns is a horizontal box, Assessments: baseline; after treatment; short term (< 3 months); Intermediate (< 6 months); long term (> 6 months).

## Data Sources and Literature Search Strategies

Electronic search strategies were developed and tested through an iterative process by an experienced medical information specialist in consultation with the UO-EPC team. We searched the following electronic databases: MEDLINE (Ovid MEDLINE(R) In-Process & Other NonIndexed Citations); MEDLINE (Ovid MEDLINE(R): 1950 to 2010 February Week 1); the Cochrane Library 2010 Issue 1 including CENTRAL, Cochrane Database of Systematic Reviews, DARE, HTA, and NHSEED; EMBASE (1980 to 2010 Week 4); CINAHL (1982 to September Week 3 2008); AMED (Allied and Complementary Medicine: 1985 to January 2010); Mantis (1880 to October 2008); EBM Reviews - ACP Journal Club (1991 to August 2008). Specialized CAM databases were also searched, including the Index to Chiropractic Literature (ILC) October 2008; Acubriefs 2008 October; Complementary and Alternative Medicine (NZ) 2008; and the LILACS Database October 2008. Some of these databases provided extensive coverage of foreign language materials (e.g., Asian, South American studies). Bibliographic records of potentially relevant nonEnglish publications were retrieved in MEDLINE, EMBASE, Central, Acubriefs, AMED, LILACS, and Mantis. There was no unique database for foreign language records. We utilized strategies combining controlled vocabulary and keywords such as Acupuncture, Electroacupuncture, Needling, Acupressure, Moxibustion, and Manipulative Medicine. The searches were not restricted to any language or date. Additional potentially eligible references were sought through hand-searching the bibliographies of relevant items. (Appendix A)

We identified unpublished literature through searching the Web sites of relevant specialty societies and organizations, health technology assessment agencies, economic research institutions, guideline collections, trial registries, and conferences.

## Study Selection

To assess relative benefits and harms as well as cost-effectiveness of CAM treatments’ (i.e., acupuncture, manipulation, mobilization, massage, and flexion-distraction technique) use in adults (age ≥ 18 years) with back, neck, headache, or thoracic pain (acute, sub-acute, chronic, mixed duration), we selected primary reports of comparative efficacy/harms and economic evaluation from randomized controlled trials (RCTs). Trials including participants with pain due to specific or nonspecific causes were eligible for inclusion in the review. Additionally, nonrandomized controlled trials and observational studies (e.g., cohort, case-control, cross-sectional studies) reporting comparative data on long-term (> 6 months) harms were eligible for inclusion.

Control (comparator) treatments included no treatment, placebo (sham), or any other active treatment (e.g., CAM therapy, medication, physiotherapy, ultrasound, exercise, heat/cold therapy, electrotherapy, spinal mechanical traction, spinal injection, aquatic therapy). Trials using combination of CAM with other ‘active therapy’ versus the same ‘active therapy’ were included only if the effect of CAM alone was ascertained, based on the assumption of no interaction between the CAM and the ‘active therapy’. Trials using a combination of manipulation and mobilization in an experimental arm were also included in the review.

The review of non-English publications was limited to German, Dutch, Chinese, Japanese, Italian, French, Portuguese, and Spanish. We included relevant unpublished literature in the review. Systematic and narrative reviews, case reports, editorials, commentaries or letters to the editor were excluded.

The results of the literature search were uploaded to the software program TrialStat SRS version 4.0 along with screening questions developed by the review team and supplemental instructions. A calibration exercise was undertaken to pilot and refine the screening process. Initially, two independent reviewers screened titles and abstracts of all identified bibliographic records (screening level I). Then the same reviewers retrieved and reviewed full-text reports of all potentially eligible records (screening level II). Discrepancies at both screening levels were discussed and resolved by consensus.

The literature selection process, including reasons for exclusions, is presented in the PRISMA study flow diagram (Chapter 3, Figure 2).

## Data Abstraction

Two reviewers independently abstracted relevant information from each included study using an a priori developed abstraction form. The abstracted data were crosschecked and conflicts were resolved by consensus. The abstracted data included study characteristics (study author, design, sample size, country), type of experimental treatment (e.g., acupuncture, spinal manipulation), type of control treatment (e.g., pain medication, neck exercise, traction, sham-acupuncture, advice, education, no treatment/waiting list), treatment-related factors (e.g., spine region of administration, frequency, number of sessions, dose, specific acupoints, depth/duration of needle insertion, electrical stimulation of needles, mechanically assisted manipulation, manual acupuncture), baseline population characteristics (e.g., age, gender, race, pain location/extension, duration of pain, cause of pain, pain severity, comorbidities), and treatment provider-specific factors (e.g., years of education/experience, specialization, training).

The abstracted data for each continuous outcome included: mean (or median), standard deviation (and/or standard error), and 95 percent confidence interval (95 percent CI). For dichotomous outcomes, proportions and corresponding 95 percent CIs were abstracted.

Primary efficacy/effectiveness outcomes that were abstracted were: pain intensity (e.g., Visual Analog Scale-VAS, Numerical Rating Scale-NRS, McGill Pain Questionnaire-MPQ, Von Korff Chronic Pain Grade Scale), function (Hannover Functional Ability Questionnaire-HFAQ) and disability (e.g., Roland Morris Disability Questionnaire-RMDQ: 0-24, Northwick Park Neck Pain Questionnaire-NPQ: 0-36, modified NPQ: 8 items 0-32, Oswestry Disability Index: 0-50, Activities of Daily Living-ADL, Neck Disability Index-NDI: 0-50, and Pain Disability Index-PDI) well being/quality of life (e.g., EQ-5D, SF-36 physical functioning or pain domains), global perceived effect (GPE), work related outcomes (e.g., work absenteeism, sick leave), and conventional health care utilization (e.g., number of visits to health care services, intake of pain medications).

Secondary efficacy/effectiveness outcomes considered for abstraction included spinal range of motion (ROM; flexibility, extension, rotation), straight leg raise (SLR), finger floor distance (FFD), and muscle strength.

The timing of post-treatment followup for each outcome was ascertained and then categorized into four groups: immediate, short- (< 3 months), intermediate-(3 months to 12 months), and long-term (> 12 months) post-treatment followup.

For cost-effectiveness analysis, the following data was extracted: a) costs in the health care sector, b) costs of production loss, c) costs in other sectors, d) patient and family costs, and e) total costs.

Any data on harms was also abstracted (i.e., proportion of patients with at least one event). We considered the following harms outcomes: any adverse events, serious adverse events, withdrawals due to adverse events, and specific adverse events (e.g., increase in pain, bruising, local bleeding, infection, punctured organs, swelling, allergies, cauda-equina syndrome).

## Assessment of Study Quality and Reporting

The risk of bias for RCTs was assessed using the criteria list recommended in the Updated Method Guidelines for Systematic Reviews in the Cochrane Collaboration Back Review Group.8 The tool is shown in Appendix F.

For each study, a criterion was rated as "yes", "no" or "don't know". The quality of individual studies were classified into three groups (i.e., good, fair, and poor), depending on the number of ‘Yes’ ratings across the following four domains (questions 2, 3, 4, and 9 of risk of bias tool): a) treatment allocation concealment (selection domain), b) balance of baseline characteristics between the groups (selection domain), c) patients’ blinding status to the intervention they received (blinding domain), and d) number/reasons for dropouts/withdrawals (attrition domain). For example, studies with scores of 0-1, 2-3, and 4 (i.e., number of ‘yes’ ratings on four domains) were classified as having poor, fair, and good quality, respectively.

To explore overall bias, we constructed risk-of-bias graphs that are presented in the Results sections.8

Studies of other designs were assessed using the modified tool suggested by Downs and Black.9 The items of this tool cover the following constructs: selection of study population, comparability of study groups (important confounders controlled for through either matching and/or adjusting in the analysis), and ascertainment of outcomes (independent blind assessment, sufficient length of followup).

Additionally, methodological quality of the included economic studies was determined using the CHEC list. This list consists of 19 items for the assessment of the quality of economic evaluations conducted alongside randomized clinical trials that were selected in a Delphi process by 23 experts in the field of health economics (see Appendix F).10

## Rating the Strength of Evidence

We assessed the overall strength of evidence using the approach of grading system suggested by the Evidence-based Practice Center (EPC) program of the U.S. Agency for Healthcare Research and Quality (AHRQ).11 This system is largely based on the Grading of Recommendations Assessment, Development, and Evaluation (GRADE) working group approach. 12 The evidence grading method consists of four major domains: 1) risk of bias (aggregate measure of the overall quality or degree of bias of study/studies for a given outcome or comparison), 2) consistency (the degree to which results of studies for a given outcome or comparison are uniform in terms of effect direction and statistical significance), 3) directness (whether or not the interventions were compared in head-to-head trials; ultimate health outcomes versus surrogate outcomes), and 4) precision (the degree of variability/uncertainty around the pooled effect estimate).

The overall quality of evidence (risk-of-bias) for a given outcome was derived from the quality scores of individual study or studies (poor, fair, or good) and was categorized in three groups (high, medium, or low). If evidence consisted of only one study (or multiple studies of the same quality rating), then the study quality corresponded to risk-of-bias for this evidence in the following manner: study quality (poor) = risk-of-bias (high), study quality (fair) = risk-of-bias (medium), and study quality (good) = risk-of-bias (low). In case of evidence consisting of multiple studies with different quality ratings (studies of poor, fair, and good quality mixed together), the mean quality score (i.e., mean number of ‘Yes’) was calculated. Evidence with mean quality score < 2 was labeled as having high risk of bias, 2 ≤ mean quality score < 4 was labeled as having medium risk of bias, and the mean quality score of 4 was labeled as low risk of bias. The relationship between the risk of bias for evidence and mean quality score based on individual study (or studies) is presented in Table 1.

Table 1 Study quality and risk-of-bias

Quality score^*^ | Study Quality | Risk of Bias
0 ≤ N < 2 | Poor | High
2 ≤ N < 4 | Fair | Medium
N = 4 | Good | Low

* Number of ‘Yes’ on 4 domains; in case of a single study, N is a whole number (0, 1, 2, 3, 4); in case of multiple studies, N is a mean number which may be whole number or fraction

Depending on ratings for four domains (risk of bias, consistency, directness, and precision), the grade of evidence was high, moderate, low, or insufficient (Table 2). The initial high grade was reduced by one level (from high to moderate; from moderate to low grade) for each of the domains not met: risk of bias (medium), consistency (inconsistent, single trial-not applicable), precision (imprecise), and directness (indirect). The grade was reduced by two levels from high to low in case of high risk of bias. Although we ascertained and presented ratings for ‘precision’ in the tables for specific outcomes, we did not downgrade the strength of evidence based on this domain simply due to the absence of a pooled estimate and 95 percent confidence intervals. The absence of evidence was graded as ‘insufficient’. Results were considered consistent when statistically significant or nonsignificant effects in the same direction were observed across trials. The pooled estimate with relatively narrow range of effect sizes (95 percent confidence intervals) with clear direction leading to clinically uniform conclusion was considered as ‘precise evidence’. Clinical outcomes such as pain, disability or function, quality of life, proportion of subjects who improved, time to (or duration of) analgesic effect, and use of analgesics were considered as ‘direct evidence’. Other measures such as range of motion (ROM), pressure pain threshold (PPT), utilization of conventional healthcare system (e.g., general practitioner visits, imaging studies), sick leave (e.g., length, proportion of subjects), and proportion of subjects cured were considered as ‘indirect evidence’. The grading results for strength of evidence are presented throughout the Results section (Chapter 3, Tables 5, 7, 9, 12, 13, 15, 17, 19, and 21). For reasons of brevity, these tables do not include trials comparing benefits/harms of CAM treatments combined with other therapies (except for manipulation plus mobilization in experimental arm), or trials comparing different modalities of the CAM treatments (manipulation daily versus manipulation weekly; deep acupuncture versus superficial acupuncture).

Table 2 Grading of evidence

Grade | Domain
High | All 4 domains are met (e.g., low risk of bias, precise, direct, consistent)
Moderate | 1 of the domains is not met (e.g., medium risk of bias, precise, direct, consistent)
Low | 2-4 of the domains are not met (e.g., high risk of bias, precise, indirect, inconsistent)
Insufficient | No evidence/absence of evidence

The graded evidence is presented in the results section. (Chapter 3)

## Evidence Synthesis and Analysis

The results (both quantitative and qualitative parts) of this review were grouped according to a type of experimental intervention (e.g., acupuncture, manipulation, mobilization, massage), pain location in spinal region (low back, neck, head, thorax), duration of pain (acute/sub-acute, chronic, mixed, unknown), and cause of pain (specific versus nonspecific).

The results of all analyses for any given outcome (e.g., pain, global measure, function, disability, harms, medication use) were presented within subgroups defined by location, duration, and cause of pain, and were presented separately with respect to control intervention (e.g., no treatment, placebo, other CAM treatment, medication, other treatment) and timing of outcome ascertainment during post-treatment followup (immediate, short-, intermediate-, and long-term).

### Qualitative Analysis

For each study, information on sample size, demographics (e.g., age, gender, race), settings (e.g., population-based, primary care, hospital), treatments (type, dose, frequency, and experience of the caregiver), outcomes (e.g., pain, disability, function, medication use), and source of funding (e.g., industry, government) were summarized in text and/or summary tables. The results of one or more trials that compared two or more treatments with respect to change in any given outcome were summarized in text as well as in numerous tables. (Refer to Chapter 3).

### Quantitative Analysis

The decision to pool individual study results was based on clinical judgment with regards to comparability of study populations, treatments, and outcome measures. We considered studies suitable for pooling if they used the same design (RCT), enrolled similar populations (e.g., chronic specific neck pain), evaluated the same types of treatments (e.g., acupuncture versus placebo; manipulation versus no treatment), and reported the same outcomes measured with identical scale and ascertained in similar post-treatment followup periods (e.g., pain intensity on VAS immediately after the treatment). The meta-analyses of pain were based on 1-10 visual analogue scale. We used DerSimonian and Laird random-effects models to generate pooled estimates of relative risks (RRs) and weighted between-group end point mean differences (WMDs) with 95 percent CIs.13 Statistical heterogeneity was evaluated using a chi-square test and the I^2^ statistic (low: 25.0 percent; moderate: 50.0 percent; high: 75.0 percent).8

When studies did not report summary statistics (e.g., mean score, standard deviation, standard error) adequately, we calculated the needed parameters if data for individual patients were reported. If a study reported only a standard error of the mean response, we converted it to a standard deviation. Trials were not incorporated into meta-analyses if the needed data (e.g., mean and standard deviation) could not be derived. Trials with obvious between-group baseline imbalances in the outcome were not pooled unless the mean change from baseline and corresponding SDs for the compared study groups were reported.

If data allowed, the statistically significant pooled estimates of post-treatment pain intensity and disability were planned to be examined in order to determine the degree of clinical importance for the observed differences between the treatment groups. The assessment of the degree of clinical importance was based on the criteria from the updated methods guideline for systematic reviews suggested by the Cochrane Back Review Group which were defined as small (WMD < 10 percent of the VAS or a disability scale), medium (10 percent ≤ WMD < 20 percent of the VAS or a disability scale), and large (WMD ≥ 20 percent of the VAS or a disability scale).14

We examined the extent of publication bias through visual inspection of funnel plot asymmetry with respect to contours of statistical significance (Moreno et al. 2009)15 and the Egger’s regression-based method.16

### Subgroup and Sensitivity Analyses

We planned to conduct subgroup and sensitivity analyses to explore statistical heterogeneity, if the collected data allowed. The a priori defined population subgroups were based on patient-specific factors (age, gender, race, education, comorbidity). Trial-specific factors were study quality (risk-of-bias) and type of treatment provider. To explore the impact of study quality on the pooled effect estimate between two treatments, trials were categorized into two groups: ‘higher risk-of-bias’ and ‘lower risk-of-bias.’ If for a trial, seven or more items of the risk-of-bias tool were rated as ‘Yes’ this trial was categorized into ‘lower risk-of-bias’ group, otherwise into ‘higher risk-of-bias’ group. Afterwards, the pooled treatment effect estimates across the two strata of trials with ‘lower risk-of-bias’ and ‘higher risk-of-bias’ were compared in terms of their effect size, direction, statistical significance, and 95 percent CI.

We performed all analyses using R software, version 2.4.0 (www.r-project.org).