# Summary Tables

## Low Back Pain

Table 1.1 Low Back Pain - Acupuncture – Acute/Sub-acute - Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Huang, SR (2006)1 China | 98 | % male: 49.8% Mean age: 44.5 yrs | L4/5 Disc herniation or with other disc herniation; Age<65yrs; Duration of pain≤2w; Non-use of glucocorticoid and nonsteroidal anti-inflammatory drugs in the study period | 1. local single-point electro-acupuncture, treatment provider NR n = 53; 2. routine electro-acupuncture, n = 45 | 2 treatments/Week 4 weeks | 1. Disability: Oswestry disability index; 2. ADVERSE EVENTS: no harms reported; Data measured at 4 weeks | 4/13
Lai, Y (2004)2 China | 76 | % male: NR Mean age: NR | Diagnostic using Chinese New Medicine Clinical Trial Reference 1993 ref[2] | 1. acupuncture Xi-cleft and normal points, treatment provider NR n = 41; 2. acupuncture normal points, n = 35 | 1 treatment/day 20 treatments | 1. Pain: VAS; 2. Quality of Life: Well being, Chinese Standard; 3. ADVERSE EVENTS: no harms reported; Data measures at 20 days | 4/13
Wen-Jun, L (2000)3 China | 238 | % male: 84.5% Mean age: NR | Patients with acute lumbar sprain | 1. acupuncture-treatment, treatment provider NR n = 112; 2. acupuncture-control, n = 126 | 5 treatments NR | Response rate; 1. ADVERSE EVENTS: no harms reported | 2/13

Table 1.2 Low Back Pain - Acupuncture – Acute/Sub-acute - Non –Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Kennedy, S (2008)4 Northern Ireland | 48 | % male: 47.95% Mean age: 45.55 yrs | 18-70 yrs adults with non-specific LBP, with/out referred pain, up to 12 weeks duration. Acute/sub-acute | 1. Acupuncture (verum), by senior experienced physiotherapists, n = 24; 2. Sham Acupuncture, by same senior experiences physiotherapists as intervention group n = 24 | Maximum 12 treatment in total 6 weeks | 1. Pain: VAS (average and worst); 2. Disability: Roland Morris Disability Questionnaire; 3. Quality of Life: NR; 4. Work: work absenteeism; 5. Utility of conventional care: medication use (tablets/day); 6. ADVERSE EVENTS: no harms reported; Data measured at baseline, 6 weeks and 3 mo | 8/13
Eisenberg, DM (2007)5 US | 434 | % male: 47.5% Mean age: 42.95 yrs | Patients with acute LBP for 21 d or less aged > 18 yrs | 1. acupuncture, by 11 acupuncturists, n = 58; 2. chiropractic, by 9 chiropractors, n = 76; 3. massage, by 12 massage therapists, n = 152; 4. usual care, n = 148 | 10 sessions total 5 weeks | 1. Pain: bothersomeness of worse symptom;; 2. Disability: Roland Morris Disability Questionnaire; 3. Quality of Life: physical and mental SF-12; 4. ADVERSE EVENTS: minor discomfort/soreness; Data measured at immediate post-treatment | 8/13
Wenzhong, C (2001)6 China | 400 | % male: 33.8% Mean age: NR | Patients with acute lumbago (severe and very severe pain) who sought medical advice from Department of Acu and Moxi and the surgical Department of Orthopedics | 1. acupuncture with filiform needle, n = 100; 2. acupuncture with filiform needle + cupping, n = 100; 3. acupuncture with filiform needle + pricking collateral + cupping, n = 100; 4. acupuncture with filiform needle + pricking collateral + cupping + Moxibustion, n = 100; Treatment provider : NR | 5 or 10 times of separate treatment, once/2 days 6 hrs-9 days | 1. Quality of Life: curative effect at 5 and 10 treatments; 2. ADVERSE EVENTS: no harms reported; Data measured at 5 and 10 treatments | 0/13
Araki, S (2001)7 Japan | 40 | % male: 70% Mean age: 43.8 yrs | Patients with acute LBP (who have gait disturbance; information from author) | 1. acupuncture by 2 acupuncturists with 3 and 6 years experience, n = 20; 2. sham acupuncture by same therapists = 20 | Single treatment | 1. Pain: VAS (mm) of pain and LBP score by JOA; 2. Disability: JOA score; 3. ADVERSE EVENTS: no harms reported; Data measured after single treatment | 10/13
Kittang, G (2001)8 Norway | 60 | Male (%): NR Mean age: NR (range 18 – 67 years) | Patients withnon-radiating acute low-back pain (lasting less than 10 days). | 1. Acupuncture, n = 30; 2. Medication, n = 30; Co-intervention: advice and exercise Treatment provider: NR | 4 sessions 2 weeks | 1. Pain (VAS); 2. use of other pain medication; 3. number of back pain episodes at 6, 18 months; 4. stiffness measured at baseline 1, and 2 weeks, and 3 and 6 months; 5. ROM (lateral flexion); 6. Harms at 1 and 2 weeks | 7/13

Table 1.3 Low Back Pain - Acupuncture - Chronic - Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Itoh, K (2004)9 Japan | 35 | % male: 28.6% Mean age: 71.9 yrs | Patients with lumbar or lumbosacral LBP of ≥ 6 mo, aged ≥ 65 yrs, no radiation of LBP, normal neurological examination, no previous Treatment with Acu for LBP | 1. superficial-acupuncture (trigger points), by acupuncturist with 4 yrs training and 7 yrs experience, n = 12; 2. deep-acupuncture (trigger points by the same therapist = 10; 3. STD-acupuncture (traditional points), by same therapist, n = 13 | 6 weeks | 1. Pain: VAS pain intensity; 2. Disability: Roland Morris Questionnaire; 3. ADVERSE EVENTS: no harms reported; Data measured at 6 weeks | 7/13
Ceccherelli, F (2001)10 Italy | 42 | % male: 71% Mean age: 41.64 yrs | Normal deep tendon reflexes at lower limbs; negative Laseque and Wassermann test findings; Patients with radiographic evidence of arthritis; negative CT scan findings for disc bulging; normal EMG results | 1. deep acupuncture, by medical licensed acupuncturists, n = 21; 2. superficial acupuncture, n = 21 | 8 session total 6 weeks | 1. Pain: McGill pain questionnaire-number of words; total score; 2. ADVERSE EVENTS: no harms reported; Data measured at 6 weeks and 3 mo | 9/13
Gunn, CC (1980)11 Canada | 56 | % male: 100% Mean age: 40.6 yrs | Male workers disabled from injury for at least 12 weeks; disabling pain despite traditional medical or surgical treatment ; disability periods 12-168 weeks | 1. acupuncture + standard care, by acupuncturist n = 29; 2. standard care by general practitioner, n = 27 | Maximum of 15 treatments8 weeks | 1. Pain: pain + work status questionnaire: full recovery; partial recovery; slight recovery; no recovery; 2. ADVERSE EVENTS: no harms reported; Data measured at 8, 12 and 12-6 weeks, mean 27.3 weeks | 4/13

Table 1.4 Low Back Pain - Acupuncture - Chronic - Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Haake, M (2007)12 Germany | 1162 | % male: 40.43% Mean age: 50.03 yrs | > 18 yrs old adults with chronic LBP for ≥ 24 weeks | 1. Acupuncture (verum), by physicians of various specializations with median of 8 yrs practice n = 387; 2. Sham acupuncture (placebo) by same physicians, n = 387; 3. standard therapy, n = 388 | Up to 7 weeks | 1. Pain: CPGS; 2. Disability: HFAQ (treatment responses 12% or better); 3. Quality of Life: SF-12 (physical score); patient global assessment; 4. ADVERSE EVENTS: not relevant for abstraction; Data measured at 3 and 6 mo | 10/13
Inoue, M (2006)13 Japan | 31 | % male: 67.9% Mean age: 69 yrs | Patients consulted for LBP, newly referred and those re-attending, with only LBP in a limited area, which was exacerbated in particular posture | 1. acupuncture by acupuncturists, n = 15; 2. sham acupuncture by same therapists, n = 16 | NR | 1. Pain: VAS; 2. Disability: range of lumbar spinal flexion; 3. ADVERSE EVENTS: no harms reported | 9/13
Witt, CM (2006)14 Germany | 2841 | % male: 42.7% Mean age: 52.85% | Clinical diagnosis of chronic LBP lasting more than 6 months; age 18 or over, provision of written informed consent | 1. acupuncture by physicians with A-diploma of 140 hrs acu education, n = 1451; 2. control: no treatment, n = 1390 | Maximum of 15 acu treatment 3 months | 1. Pain: back pain score; % reduction of pain; 2. Disability: HFAQ; 3. Quality of Life: SF-36; 4. Cost: incremental cost effective per quality adjusted life year-overall; 5. ADVERSE EVENTS: reported for Acu group but no details; Data measured at 3 and 6 mo | 7/13
Itoh, K (2006)15 Japan | 26 | % male: NR Mean age: 76.15 yrs | Patients at least 65 yrs with history of LBP-lumbar/lumbos acral pain for at least 6 mo; leg pain; | 1. trigger point acupuncture by acupuncturist with 4 yrs training and 7 yrs clinical experience, n = 13; 2. sham by same therapist, n = 13 | 36 treatments total 12 weeks | 1. Pain: VAS 10 cm scale; 2. Disability: Roland Morris Questionnaire (24 questions); 3. ADVERSE EVENTS: no harms reported; Data measured at 12 weeks | 8/13
Brinkhaus (2006)16 Japan | 295 | % male: 30.97% Mean age: 58.73 yrs | Clinical diagnosis of CLBP with a disease of more than 6 mo; 40-75 yrs; average pain intensity of 40 or more; written consent; use of oral non-steroidal anti-inflammatory drugs in 4 weeks before treatment | 1. acupuncture by acupuncture physicians with at least 3 yrs experience and 140 hrs of acu training, n = 145; 2. minimal acupuncture or sham by same physicians, n = 71; 3. waiting list group, n = 79 | 12 sessions total 8 weeks | 1 Pain: VAS score (pain intensity); PDI score; 2 Disability: FFbH-R scores; SF-36: physical component; 4 Quality of Life: SF-36 – physical health; 5 Utility of conventional care: analgesics use in weeks 5 - 8 (diary), days; 6 ADVERSE EVENTS: details not reported; Data measured at 8 weeks, 2 mo, 6 months and 1 yr | 8/13
Giles, LG (2003)17 Australia | 115 | % male: 54.93% Mean age: 26.1 yrs | Patients at least 17 yrs; uncomplicated mechanical spinal pain for 13 weeks minimum-for long-term fu > 1 yr; those who received their randomly allocated treatment regimen during treatment period | 1. acupuncture(LB, NP, thorax), n = 36; 2. spinal manipulation, n = 36; 3. medication that has not been tried by Patients in this group, n = 43 | Maximum of 9 weeks | 1. Pain: pain frequency; VAS intensity; 2. Disability: Oswestry Disability; 3. Quality of Life: SF-36; 4. ADVERSE EVENTS: hematoma and bleeding, n = 1 committed suicide; Data measured at 9 weeks and 1 yr | 6/13
Sator-Katzenschlager SM (2004)18 Austria | 61 | % male: 0.299-verify Mean age: 53.6 yrs | Lumbar LBP of at least 6 mo; normal neurological function of lumbosacral nerved; no pain radiation; persisting pain intensity VAS ≥5 | 1. Auricular electro-acupuncture, n = 31; 2. Auricular acupuncture, n = 30; Treatment provider : NR | 6 weeks | 1. Pain: VAS pain intensity; 2. Quality of Life: well being; 3. Work: Patients on sick leave who returned to full-time work at 3 mo; 4. Utility of conventional care: consumption of tramadol rescue medication; 5. ADVERSE EVENTS: no harms reported; No numerical data Data measured at 6 weeks | 9/13
Chu, J (2004)19 US | 36 | % male: 50% Mean age: 53.4 yrs | Patients with chronic LBP (duration=> 3 mo) | 1. E-MS (ETOIMS) by trained physician, n = 12; 2. MS by trained physician, n= 12; 3. SS by trained physician, n = 12 | NR | 1. Pain: VAS pain intensity; 2. ADVERSE EVENTS: no harms reported; Data measured at 1 and 2 weeks post-treatment | 7/13
Cecherelli, F (2003)20 Italy | 31 | % male: 29% Mean age: 49.36 yrs | Patients with chronic “lombalgia” meaning LBP (pain greater than 3 months) | 1. acupuncture 5×/week; 2. acupuncture 10×/week; Treatment provider: Not specified, but author is from anesthesia department | 1. 5 weeks; 2. 10 weeks | 1. Pain: pain monitored with daily self-rating chart; final pain change relative to original pain (%); 2. ADVERSE EVENTS: no harms reported; No numerical data | 7/13
Meng, CF (2003)21 US | 55 | % male: 39.75% Mean age: 71 yrs | chronic non specific LBP > 12 weeks; age 60 years or more; radiography within past year | 1. acupuncture, n = 31; 2. usual care, NSAIDS, analgesics, exercises, n = 24; Treatment provider: NR | 10 sessions total 4 weeks | 1. Pain: VAS with word anchors-ITT; 2. Disability: mRDQ - ITT; 3. Quality of Life: global transition scale; Data measured at 4, 6 and 9 weeks | 7/13
Kerr, P (2003)22 Northern Ireland | 46 | % male: 47.3% Mean age: 40.5 yrs | LBP symptoms > 6 mo; with or without leg pain; no neurological deficits; patients had to be happy to have acupuncture or another treatment; willing to participate in trial and undergo assessment procedures | 1. acupuncture by chartered physiotherapist trained in acu, n = 26; 2. placebo-TENS by same therapist, n = 20; 3. non-attendees (drop outs), n = 0 | 6 weeks | 1. Pain: McGill Pain Questionnaire; VAS (mm);; 2. Quality of Life: SF-36- duration of pain relief; 3. ADVERSE EVENTS: no harms reported; Data measured at 6 weeks and 6 mo | 4/13
Yeung, KN (2003)23 Hong Kong | 52 | % male: 17.3% Mean age: 53 yrs | Patients with chronic non- specific LBP (> 6 mo) with or without radiation- age between 18-75 yrs - 3 (12%) of group 2 had prolapsed intervertebral disc | 1. electro-acupuncture + exercise by physiotherapist certified in acu, n = 26; 2. exercise by same therapist, n = 26 | 4 weeks | 1. Pain: NRS- average pain; worst pain; 2. Disability: Aberdeen LBP scale(0-100 points); 3. ADVERSE EVENTS: n = 1 had a stroke before 3 months fu; Data measured at 4 weeks and 3 mo | 7/13
Molsberger, AF (2002)24 Germany | 186 | % male: 47.9% Mean age: 49.3 yrs | LBP (pain between 12^th^ rib and gluteal fold); with pain for at least 6 weeks; average pain score of at least 50 mm on 100 mm VAS during last week; 20-60 yrs; ability to communicate in German | 1. verum acupuncture + conventional orthopaedic therapy by experienced medical doctor, n = 65; 2. sham acupuncture + conventional orthopaedic therapy by same doctor, n = 61; 3. nil + conventional orthopaedic therapy, n = 60 | 6 weeks | 1. Pain: VAS mean pain intensity (ITT); 2. Quality of Life: PBS: rated effectiveness of the treatment protocol; Data measured at 6 weeks and 3 mo | 3/13
Leibing, E (2002)25 Germany | 131 | % male: NR Mean age: 48.1 yrs | Non-radiating pain for more than 6 months. Age 18-65 years | 1. combined traditional body and ear acupuncture + physiotherapy by experienced Taiwanese physician, n = 40; 2. physiotherapy by trained physiotherapist, n = 45; 3. sham acupuncture + physiotherapy by same investigators in other groups, n = 46 | 20-26 sessions total 12 weeks | 1. Pain: VAS (10 cm) –pain intensity; PDI (total score = 70); 2. ADVERSE EVENTS: n = 2, painfulness of acupuncture; n = 1, problem with circulation; Data measured at 12 weeks and 9 mo | 2/13
Carlsson, CPO (2001)26 Sweden | 50 | % male: 34% Mean age: 49.5 yrs | Lumbar or lumbosacral LBP for at least 6 mo; no radiation of pain below knee; normal neurological exam findings of lumbosacral nerve function | 1. manual acupuncture, n = 18; 2. electro-acupuncture, n = 16; 3. TENS, n = 16; Treatment provider: NR | 8 weeks | 1. Pain: VAS- pain intensity in the morning; in the evening; 2. Quality of Life: Global assessments; Data measured at 8 weeks, 1 and 3 mo | 6/13
Cherkin, DC (2001)27 US | 262 | % male: 41% Mean age: 44.9 yrs | Ages 20 to 70 years who visited a primary care physician for low back pain who had persistent LBP for 6 weeks | 1. acupuncture by licensed acupuncturists with at least 3 yrs experience, n = 94; 2. massage-manipulation of soft-tissue by licensed therapists with at least 3 yrs experience, n = 78; 3. self care education, n = 90 | Up to 10 visits 10 weeks | 1. Pain: symptom bothersomeness during past week; 2. Disability: Roland Disability Scale Score; National Health Interview survey; 3. Quality of Life: SF-12 mental health summary scales; 4. ADVERSE EVENTS: no harms reported; Data measured at 10 weeks and 1 yr | 6/13
Grant, DJ (1999)28 UK | 60 | % male: 10.26% Mean age: 73.5 yrs | Patients at least 60 yrs old with complain of back pain of at least 6 months duration | 1. acupuncture by physiotherapist, n = 32; 2. TENS by same therapist, n = 28 | 8 sessions total 4 weeks | 1. Pain: VAS (IQR); NHP; 2. Utility of conventional care: tablets consumed in last week (IQR); 3. Quality of Life; 4. ADVERSE EVENTS: drop outs: n = 2, influenza and immobility; n = 1, acute depression; Data measured at 4 weeks, 4 days post treatment and 3 mo | 6/13
Lehmann, TR (1983)29 US | 53 | % male: 67% Mean age: 39 yrs | Patients with chronic disabling LBP who demonstrate at least minimal levels of motivation and in whom the level of disability would warrant the expense of inpatient treatment | 1. electro-acupuncture by certified and experienced acupuncturist, n = 17; 2. TENSE by experienced physical therapist, n = 18; 3. sham TENSE by same provider as in group 2, n= 18 | 3 weeks | 1. Pain: peak pain; average level of pain; 2. Return to work; 3. ADVERSE EVENTS: no harms reported; Data measured at 3 weeks and 3-6 mo | 1/13
MacDonald, AJR (1983)30 UK | 17 | % male: 29% Mean age: NR | Patients with chronic LBP which had failed to derive relief from conventional methods; referred BP for at least one year. | 1. elecrto-acupuncture, n = 8; 2. sham electro-acupuncture, n = 9; Treatment provider: NR | 1 treatment/week NR | 1. Pain: %, pain relief; pain score reduction; activity pain score reduction; physical signs reduction; combined average reduction; 2. ADVERSE EVENTS: no harms reported; Data measured at before each treatment | 2/13
Mendelson, G (1983)31 Australia | 77 | % male: 48.4% Mean age: 54.1 yrs | Chronic LBP; no Litigation or compensation claims pending; no overt psychiatric illness; ability to read and write in English | 1. Acupuncture/placebo by surgeon, n = 36; 2. Placebo/Acupuncture by same surgeon, n = 41 | 2 treatment/week 4 weeks | 1. Pain: VAS 100 mm; McGill Pain Questionnaire (PRI, PPI); 2. ADVERSE EVENTS: no harms reported; Data measured at 4 weeks | 6/13
Coan, R (1980)32 US | 50 | % male: 46.3% Mean age: 46.9 yrs | LBP for 6 months or more; No previous acupuncture treatments; no history of diabetes, infection or cancer; not more than 2 back surgeries | 1. acupuncture-immediate, n = 23; 2. acupuncture-delayed (control), n = 16; 3. acupuncture-inadequate, n = 11; Treatment provider: NR | NR | 1. Pain: VAS 10 cm; 2. ADVERSE EVENTS: no harms reported; Data measured at 3 and 6 mo | 3/13
Mendelson, G (1978)33 Australia | 77 | % male: 48% Mean age: 53.5 yrs | Chronic LBP; no Litigation or compensation claims pending; no overt psychiatric illness; fluent in English; referred by their attending doctor | 1. acupuncture, n = 36; 2. placebo (sham acupuncture), n = 41; Treatment provider: NR | 2 treatment/week 4 weeks | 1. Pain: VAS 100 mm for pain; 2. ADVERSE EVENTS: no harms reported; Data measured at 4 weeks | 1/13
Fu, ZH (2006)34 China | 60 | % male: 47% Mean age: 56.1 yrs | Adults 20-60 years old with chronic LBP (between the 12th rib and gluteal fold) | 1. Fu’s subcutaneous needling (FSN), n = 32; 2. minimal needling, n = 28; Treatment provider: NR | NR | 1. Pain: VAS: motion related pain (MRP); pain under pressure (PUP); 2. ADVERSE EVENTS: n = 1, fainted during intervention; n = 11, bleeding after intervention; n = 6, hurt feeling during needling manipulation; Data measured at B | 3/13
Nan, L (2005)35 China | 360 | % male: NR Mean age: 46 yrs | Patients age 18- 65 yrs with lumbar strain in reference with relevant standard implementation in Traumatology in Chinese Medicine; (from Department of Pain) | 1a dermal needling, n = 88; 1b – dermal needling, n = 92; 2a body acupuncture, n = 91; 2b – body acupuncture, n = 89; Treatment provider: NR | 1. 10 treatment sessions total; 2. 14 treatment sessions total | 1. Pain: Patients with no pain at the end of two courses; Patients with grade II pain; 2. ADVERSE EVENTS: n = 3, pain during tapping could not be tolerated (did not get treatment); Data measured at B | 3/13
Li, N (2005)36 China | 60 | % male: 43.5% Mean age: 56.5 yrs | LBP and duration of pain>1 year; age: 1870 yrs; Oswestry LBP disability index >30; Patients adhere to be follow-up | 1. acupuncture, n = 31; 2. physiotherapy, n = 29; Treatment provider: NR | One treatment/day 4 weeks | 1. Pain: overall efficiency; relapse rate; 2. Disability: Oswestry LBP disability index; 3. ADVERSE EVENTS: no harms reported; Data measured at 4 weeks and 6 mo | 4/13
Wang, BX (2004)37 Pakistan | 40 | % male: NR Mean age: 46 yrs | Patients with intervertebral disc protrusion aged => 18 yrs suffering from radiating pain to the lower limb for > 2 yrs | 1. electro-acupuncture by acupuncturist, n = 23; 2. medication by same therapist, n = 17 | One treatment/day 5-7 days | 1. Pain: VAS pain intensity at buttock; 2. ADVERSE EVENTS: no harms reported; Data measured at end of treatment period, 5-7 days | 2/13
Hollisaz, MT (2008)38 Iran | 119 | % male: 45.4% Mean age: NR | Patients with LBP of sciatica origin (> 6 mo) aged ≥ 20 yrs Chronic | 1. electro-acupuncture, n = 41; 2. physiotherapy, n = 38; 3. placebo, n = 40; Treatment provider: NR | 15 sessions in total | Percent of patients with resolved symptoms not related to LBP – irrelevant to review; 1. ADVERSE EVENTS: no harms reported | 2/13
Takeda, H (2001)39 Japan | 20 | % male: 85% Mean age: 31.1 yrs | Students of acupuncture college who are suffering from lumbago | 1. acupuncture-distal point needling, n = 10; 2. acupuncture-lumbar area needling, n = 10; Treatment provider: NR | 6 treatment sessions in total 3 weeks | 1. Pain: VAS; pain threshold at lumbar area, and foot; 2. Disability: ADL score; 3. ADVERSE EVENTS: no harms reported; Data measured at 3 weeks and 3, 5, and 7 days after each session | 5/13
Sakai, T (1998)40 Japan | 26 | % male: 27% Mean age: 52.3 yrs | Non-specific LBP | 1. acupuncture, n = 14; 2. medication (NSAID), n = 12; Treatment provider: NR | 4 sessions in total 2 weeks | 1. Pain: subjective symptoms of LBP in JOA score; pain relief score; 2. Disability: ADL in JO score; 3. ADVERSE EVENTS: no harms reported; Data measured at 1 week after start of all treatments and 2 weeks | 0/13
Yu, W (1997)41 China | 200 | % male: NR Mean age: NR | Pain in waist and leg | 1. acupuncture local point, n = 103; 2. acupuncture local and Weizhong point, n = 97; Treatment provider: NR | 1 treatment/day, 20 treatments/course 1 or 2 courses 20 or 40 days | 1. Quality of Life: well being; 2. ADVERSE EVENTS: no harms reported; Data measured at 20 or 40 days
Itoh, K (2008)42 Japan | 32 | % male: 37.5% Mean age: NR | Outpatients 60 yrs or older with non-specific LBP; lumbar or lumbosacral LBP for at least 6 mo; no radiation of LBP; normal neurological findings of lumbosacral nerve; not receiving acu treatment for more than 6 mo; no change in medicine and dose for one months or longer | 1. acupuncture by acupuncturist with at least 4 yrs experience, n = 8; 2. acupuncture + TENS by same therapist, n = 8; 3. TENS by same therapist, n = 8; 4. control-topical poultice when necessary, n = 8 | 5 treatments/week 1 week total | 1. Pain: pain intensity VAS (10 cm); 2. Disability: RDQ (0-24 points); 3. ADVERSE EVENTS: WDAE, n = 1; Data measured 1, 2, 3, 4, 5 and 10 weeks | 6/13
Yuan, J (2009)43 Ireland | 30 | % male: 60% Mean age: 43.7 yrs | Subjects with chronic Non-Specific LBP | 1. acupuncture by acupuncturists with experience of > 5 yrs in clinical practice, n = 15; 2. acupuncture by same therapists, n = 15 | 1. 2 treatments/week for 5 weeks; 2. 5 treatments/week for 2 weeks | 1 Pain: VAS average; 2 Disability: RMDQ; 4 ADVERSE EVENTS: minor bleeding, n = 11; pain, n = 2; tiredness, n = 4; dizziness/headache/redness/dry mouth, n = 1; Data measured at 2 or 5 weeks, 3 and 6 mo | 9/13
Cherkin, DC (2009)44 US | 638 | % male: 40.5 Mean age: 47.2 yrs | Patients aged 18-70 yrs receiving care for chronic LBP (3-12 months) within the past yr | 1. IND-acupuncture by 6 licensed acupuncturists with 4-19 yrs experience, n = 157; 2. St-acupuncture by same therapists, n = 158; 3. sham by same therapists, n = 162; 4. usual care, n = 161 | 1-2 treatments/week 4 weeks | 1. Disability: RMDQ; 2. ADVERSE EVENTS: n = 11 Patients had moderate short-term, n = 1 pt had severe harms-no details; Data measured at 4 weeks, 3 and 6 mo | 6/13
Not yet screened (2005)45 Japan | 9 | % male: NR Mean age: NR | Patients with chronic (> 6 months) LBP | 1. acupuncture-trigger point needling, n = 4; 2. acupuncture-tender point needling, n = 5; Treatment provider: NR | Total of 5 treatment sessions 5 weeks | 1. Pain: VAS; 2. Disability: RDQ; 3. ADVERSE EVENTS: no harms reported; Data measured at 5 weeks | 5/13
Tsui MLK (2004)46 China | 42 | % male: 31% Mean age: 39.9 yrs | Patients aged 20-55 yrs with LBP radiating down to the thigh or calf for => 3 months mechanical cause but not from cancer or TB, with positive SLR findings | 1. electro-acupuncture by principal investigator , n = 14; 2. EH-acupuncture by principal investigator, n = 14; 3. exercise, n = 14 | Total of 8 sessions 4 weeks | 1. Pain: pain intensity VAS; 2. Disability: Roland Morris Disability Questionnaire; 3. ADVERSE EVENTS: no harms reported; Data measured at 4 weeks and 3 mo | 6/13
Thomas, A (1994)47 Sweden | 43 | % male: NR Mean age: NR | Patients with CLBP; sudden or insidious onset of LBP with or without trauma; duration ≥ 6 mo; recurrences with pain of variable intensity; | 1. acupuncture (manual stimulation = MS; LF electrical stimulation; HF electrical stimulation) by 2 physiotherapists trained in acu, n = 33; 2. waiting list, n = 10 | 3 treatments 6 weeks | 1. Pain: activities with <50% pain; word score; 2. Disability: subjective assessment; 3. ADVERSE EVENTS: no harms reported; Data measured at 6 weeks and 6 mo | 4/13
Kwon, Y.D (2007)48 China | 50 | % male: 33.5 Mean age: NR | Lumbar or lumbosacral pain for duration of at least 3 months; older than 20 years of age, LBP as main complaint; normal neurological examination; | 1. acupuncture, n = 25; 2. sham acupuncture, n = 25; Treatment provider : NR | 12 sessions 4 weeks | 1. Pain: VAS scores; 2. Disability: RDQ; 3. Quality of Life: PGA, patient global; 4. ADVERSE EVENTS: no harms reported; Data measured at 2 and 4 weeks | 7/13
Inoue, M (2001)49 Japan | 27 | % male: NR Mean age: 59.9 yrs | Patients with chronic lumbago who attended the university acupuncture clinic as outpatient and gave consent to attend to the trial | 1. acupuncture, n = 15; 2. sham acupuncture, n = 12; Treatment provider : NR | Single treatment | 1. Pain: VAS (10 cm) of pain at most restricted action; 2. ADVERSE EVENTS: no harms reported; Data measured after single treatment | 10/13

Table 1.5 Low Back Pain - Acupuncture - Mixed duration- Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Chen, MZ (2005)50 China | 90 | % male: 70% Mean age: 34.47 yrs | disc herniation, bone TB, tumour; pain threshold < 0.4 mA | 1. Warming needle and acupoint injection + oral medication, n = 30; 2. Oral medication, n = 30; 3. Acupoint injection, n = 30; Treatment provider : NR | 3 courses of treatment NR | 1. Quality of Life: Cured rate; total effective rate; 2. ADVERSE EVENTS: no harms reported | 4/13
Liang, SY (2008)51 China | 112 | % male: NR Mean age: NR | Patients with myofascitis LBP | 1. tendon muscle picking (acupuncture), n = 56; 2. electro-acupuncture, n = 56; Treatment provider : NR | Total of 14 sessions, 5 or 7 days each course 2 treatment courses | 1. Quality of Life: Therapeutic effect | 5/13
Hua-Sheng Tang (2008)52 China | 165 | % male: 56.9% Mean age: 40.2 yrs | Between 20-69 yrs; CLBP/traumatic LB injury; | 1. electro-acupuncture along channel by neuropathy doctor, n = 85; 2. routine acupuncture by same doctor, n = 80 | 1 session/day 40 sessions (days) total | 1. Quality of Life: Cure rate; significantly effective; effective; ineffective; total efficacy; reoccurrence; 2. ADVERSE EVENTS: no harms reported; Data measured at immediate post-NR and 6 mo | 3/13
Rui,ping She (2008)53 China | 279 | % male: 55.9% Mean age: NR | LBP; sciatica; lower limb numbness; limp intermittently; protective posture; deformity of spinal cord; straight leg raise test(+); Bragard’s test(+); dysuria or lower limb myophagism; dura mater and nerve root disturbed; MRI:interverte bral space narrow | 1. electro-acupuncture (deeply needling Qiangji 4 points) by neuropathy doctor, n = 140; 2. electro-acupuncture (routine points) by same doctor, n = 139 | 1 session/day 20 sessions (days) in total | 1. Quality of Life: Cure rate; significantly effective; effective; ineffective; total efficacy;; 2. ADVERSE EVENTS: no harms reported; Data measured at immediate post-treatment | 3/13
Mu, JP (2007)54 China | 120 | % male: NR Mean age: 39.27 yrs | Lumbar herniation; between 20-65 yrs; acute LBP less than 2 weeks after lumber herniation diagnosed; not undergoing hormonotherap y or taking steroid hormones; signed consent form | 1. Jiaji electro-acupuncture by neuropathy doctor, n = 40; 2. laser needle knife by same doctor, n= 40; 3. Jiaji electro-acupuncture + laser needle knife by same doctor, n= 40 | 1. 21 sessions total; 2. 3 sessions total; 3. 1 + 2; 1 – 3 weeks | 1. Quality of Life: SF-MPQ score; 2. ADVERSE EVENTS: no harms reported | 5/13
Qian-mei, Wu (2007)55 China | 116 | % male: 53.75% Mean age: NR | Diagnosed as lumbar herniation according to “traditional Chinese medicine diagnostic efficacy standards” Mixed | 1. needling acupoints at same nervous segment by neuropathy doctor, n = 66; 2. needling acupoints selected routinely by same doctor, n= 50 | 21 sessions in total | 1. Quality of Life: Cure rate; significantly effective; effective; ineffective; total efficacy; 2. ADVERSE EVENTS: no harms reported; Data measured at immediate post-treatment | 4/13
He, X (2007)56 China | 78 | % male: 53.85% Mean age: 45.2 yrs | Diagnosed as lumbar herniation according to Diagnosis verified with CT or MRI; Age <70 | 1. routine acupuncture + warming needle Moxibustion by neuropathy doctor, n = 39; 2. routine acupuncture by same doctor, n = 39 | 15 sessions total | 1. Quality of Life: total effective rate; incidence rate; 2. ADVERSE EVENTS: no harms reported; Data measured at immediate post-treatment | 3/13
Zhou, YL (2006)57 China | 310 | % male: 47.46% Mean age: 45.41 yrs | Disc herniation; VAS>=3; Sign a consent form; 20-65yrs | 1. ankle-three-needle, n = 162; 2. routine acupuncture, n = 76; 3. medication injection, n = 72; Treatment provider: NR | NR | 1. Pain: improvement of VAS; time of inducing analgesia; effect-lasting time; 2. Disability: straight leg raising test; 3. ADVERSE EVENTS: no harms reported; Data measured at immediate post-treatment | 5/13
Zhang, BM (2008)58 China | 200 | % male: 52.1% Mean age: 47.3 yrs | Disc herniation; 25-60 yrs old | 1. electro-acupuncture, n = 100; 2. oral medication, n = 100; Treatment provider : NR | 20 treatments (days) | 1. Pain: diagnosis and treatment of local standards; 2. Disability: lower extremity pain or numbness; ability of walking; skin sensory function of lower extremity; straight let raising test; muscle tension; 3. ADVERSE EVENTS: n = 3, local hematoma; n = 54, gastrointestinal discomfort; Data measured at 20 days | 4/13
Huang, GF (2006)59 China | 68 | % male: 58.8% Mean age: NR | Disc herniation | 1. special acupuncture, n = 36; 2. routine acupuncture, n = 32; Treatment provider : NR | 20 days (treatments) | 1. Pain: VAS; overall efficiency; level of b-endorphin, nitric oxide, superoxide dismutase and malondialdehyde in serum; 2. ADVERSE EVENTS: no harms reported; Data measured at 20 days | 6/13
Wang, N (2007)60 China | 90 | % male: 53.4% Mean age: 41.5 yrs | Disc herniation; age: 18-65yrs; Diagnosed by CT or MRI | 1. spinal manipulation, n = 45; 2. spinal manipulation + acupuncture, n = 45; Treatment provider : NR | 24 treatments (days) | 1. Pain: VAS; overall efficiency; 2. ADVERSE EVENTS: no harms reported; Data measured at 24 days | 6/13
Li, D (2006)61 China | 240 | % male: not sure Mean age: NR | Patients with lumbar disc herniation | 1. traction rotary manipulation of lumbar spine treatment, n = 80; 2. acupuncture silver needle heat conductive treatment, n = 80; 3. traction + needle heat, n = 80; Treatment provider : NR | One treatment/week 2 weeks | 1. Pain: NRS; improvement of clinical signs and curative effect; 2. ADVERSE EVENTS: no harms reported; Data measured at 3 and 6 mo | 6/13
Wang, YQ (2005)62 China | 58 | % male: 74.1% Mean age: 45.7 yrs | Disc herniation | 1. massage + spinal mobilisation + acupuncture, n = 30; 2. massage + spinal mobilisation, n = 28; Treatment provider : NR | One treatment/day 20 days | 1. Pain: VAS; overall efficiency; 2. ADVERSE EVENTS: no harms reported | 6/13
Guo, W (2005)63 | 197 | % male: 52.8% Mean age: 43.5 yrs | Disc herniation; age: 20-70y; Diagnosed by CT or MRI; Clinical Positive Signs | 1. electro-acupuncture + acupoint inject medication, n = 100; 2. spinal manipulation or spinal mobilisation + oral medication, n = 97; Treatment provider : NR | 10 days | 1. Pain: VRS; 2. Disability: angle for straight leg raising test; 3. ADVERSE EVENTS: no harms reported; Data measured at 10 days | 4/13
Xingsheng, C (1998)64 China | 198 | % male: 59.1% Mean age: 45.6 yrs | Patients with sciatica aged => 18 yrs | 1. acupuncture-point-to-point penetration + deep puncture, n = 108; 2. routine acupuncture, n = 90; Treatment provider : NR | 1-2 treatments / day 1-3 courses, 10 sessions each | 1. Quality of Life: Cured: all signs and symptoms disappeared; 2. ADVERSE EVENTS: no harms reported; Data measured at 6 mo | 2/13
Jia, Chao (2004)65 China | 82 | % male: NR Mean age: NR | Diagnosed as Cervical Spondylosis using ref[1] 1993-chinese, only those who were compliant with the treatment, only those who responded to the surveys | 1. deeply-acupuncturing Jiaji acupoint + acupoint-injection by one doctor, two are not mentioned, n = 45; 2. acupuncturing back-shu acupoint + acupoint-injection by same doctor and two others, n = 37 | 1 treatment/day 20 days | 1. Pain: VAS; McGill PRI total, feeling, sense; 2. Quality of Life: Chinese Medical Diagnostic and effectiveness standard (cure, improve, no effect); 3. ADVERSE EVENTS: no harms reported; Data measured at 20 days | 5/13
Yuan, X (2006)66 China | 144 | % male: 55.5% Mean age: NR | Patients (age ≥ 18 yrs) with Diagnosis of lumbar intervertebral disc prolapsed | 1. acupuncture, n = 78; 2. conventional medical care, n = 66; Treatment provider : NR | 1 treatment/day 45 days | 1. Pain: Hu’s criteria of curative effect; 2. ADVERSE EVENTS: no harms reported; Data measured at 45 days | 0/13
Ye, Z (2004)67 China | 56 | % male: 76.8% Mean age: 44.5 yrs | Diagnostic as lumbar intervertebral disc protrusion using CT examination and based on Shanghai Chinese Medical Diagnostic and Treatment Standard | 1. needle-knife + take Chinese medicine + therapy by hand, n = 30; 2. electro-acupuncture + take Chinese medicine + therapy by hand, n = 26; Treatment provider : NR | Total of 6 treatments | 1. Quality of Life: well being, Chinese Standard; 2. ADVERSE EVENTS: no harms reported; Data measured at end of treatment | 2/13
Ding, X (2002)68 China | 68 | % male: 33.8% Mean age: NR | Diagnosed as intervertebral disc protrusion; Only one side is in pain; Who has obvious 1 or 2 symptoms: cannot go to sleep, turn aside, walk, cough, sneeze, bowel movement, bend waist because of the pain; Pain in waist 1 Jiaji and waist 5 jiaji is in the healthy side; pain rate is ++ above | 1. injection + acupuncture on healthy side, n = 34; 2. injection + acupuncture on affected side, n = 34; Treatment provider : NR | 1 treatment/day Total of 20 treatments | 1. Quality of Life: well being, instrument was not reported; 2. ADVERSE EVENTS: no harms reported; Data measured at end of treatment | 3/13
Zhang, D (2002)69 China | 96 | % male: NR Mean age: NR | Patients with LBP due to lumbar intervertebral disc protrusion | 1. acupuncture Moxibustion + massage, n = 48; 2. acupuncture Moxibustion, n = 22; 3. massage, n = 26; Treatment provider : NR | NR | 1. Quality of Life: cure rate; effective rate; 2. ADVERSE EVENTS: no harms reported | 2/13
Zhang, Zhong-yi (2002)70 | 61 | % male: NR Mean age: NR | Diagnosed as Lumbar Intervertebral Disc Protrusion using Xray, CT or MRI | 1. acupuncture + massage, n = 30; 2. massage, n = 31; Treatment provider : NR | 2 treatments/week 10 weeks | 1. Quality of Life: well being, Chinese Medical Diagnostic and therapeutic Effective Standard; 2. ADVERSE EVENTS: no harms reported; Data measured at 10 weeks | 1/13
Ye, D (2002)71 China | 60 | % male: NR Mean age: NR | Diagnosed using Chinese Medical Diagnostic and therapeutic Standard | 1. electric-acupuncture + traction + Tuina (massage), n = 20; 2. electric-acupuncture + traction, n = 20; 3. electric-acupuncture + Tuina (massage), n = 20; Treatment provider : NR | 1 treatment/day 30 days | 1. Quality of Life: well being, Chinese Medical Diagnostic and therapeutic Effective Standard; 2. ADVERSE EVENTS: no harms reported; Data measured at 30 days | 2/13
Chen, Xiao-kai (2001)72 China | 160 | % male: NR Mean age: NR | Diagnosed as lumbar intervertebral disc prolapsed based on ref[1]-Chinese Medical Diagnostic and therapeutic Effective Standard 1994, | 1. acupuncture and Moxibustion + three-palm massage by doctors and assistants , n = 80; 2. acupuncture and Moxibustion + traction (full automatic computer traction table), providers not mentioned n = 80 | 1 treatment/day for 10 days then 1 treatment/2 days for next 20 days 30 days | None; 1. ADVERSE EVENTS: no harms reported | 4/13
Yao, Z (2007)73 China | 116 | % male: NR Mean age: NR | Diagnosed using Chinese Medical Diagnostic and therapeutic Effective Standard, | 1. acupuncture + Moxibustion, n = 62; 2. electro-acupuncture, n = 54; Treatment provider: NR | 18 treatments (days) total | 1. Quality of Life: well being, cured; 2. ADVERSE EVENTS: no harms reported; Data measured at end of treatment, 18 days | 3/13
Chen, X (2007)74 China | 88 | % male: 54.5% Mean age: NR | Diagnosed using Chinese Medical Diagnostic and therapeutic Effective Standard CT examination showed lumbar intervertebral Disc Protrusion | 1. deep acupuncture of lumbar Jiaji points, n = 44; 2. conventional acupuncture of Jiaji point, n = 44; Treatment provider: NR | 10 treatments/course 2 courses | 1. Quality of Life: well being, B, based on Chinese Medical Diagnostic and therapeutic Effective Standard; 2. ADVERSE EVENTS: no harms reported; Data measured at end of treatment | 3/13
Zeng, Y (2007)75 China | 133 | % male: 46.6% Mean age: NR | Diagnosed using Chinese Medical Diagnostic and therapeutic Effective Standard; 20-65 yr; CT or MRI examination showed lumbar intervertebral Disc Protrusion; Signed consent form | 1. abdomen acupuncture, n = 67; 2. body acupuncture, n = 66; Treatment provider: NR | 1 treatment/day 10 treatments/course | 1. Quality of Life: well being, B, based on Chinese Medical Diagnostic and therapeutic Effective Standard; 2. ADVERSE EVENTS: no harms reported; Data measured at end of treatment | 2/13
Zhong, B (2006)76 China | 60 | % male: NR Mean age: NR | Had injuries, caught cold; Waist pain complained with sciatic nerve pain; Lumbar bend, limitation on movement, pain around Jitu with radiating pain, skin nerve control too sensitive or obtuse, | 1. abdominal acupuncture + traction + body acupuncture, n = 30; 2. lumbar traction + body acupuncture, n = 30; Treatment provider: NR | NR | 1. Quality of Life: efficacy rate; 2. ADVERSE EVENTS: no harms reported | 2/13
Qu, Y (2006)77 China | 120 | % male: 56.5% Mean age: NR | Outpatients with diagnosis on syndrome of L3 transverse process (in Criteria on Diagnosis and Therapeutic Effects on Syndromes of Chinese Medicine) | 1. acupuncture with warming needles, n = 60; 2. electro-acupuncture, n = 60; Treatment provider: NR | 7 treatments total 7 days | 1. Quality of Life: therapeutic effect: cured; 2. ADVERSE EVENTS: no harms reported; Data measured at 7 days and 2 weeks | 2/13
Ye, L (2004)78 China | 98 | % male: 51% Mean age: 38.4 yrs | MRI and CT examination, using Chinese Medical Diagnostic and Therapeutic Standard for lumbar intervertebral disc | 1. hypodermic catgut embedding therapy on prolapse of lumbar intervertebral disc, n = 49; 2. electro-acupuncture, n = 49; Treatment provider: NR | 1 treatment/week 3 courses | 1. Quality of Life: well being; 2. Pain: score for symptoms somatoscopy and activity of daily life; 3. ADVERSE EVENTS: no harms reported; Data measured at end of treatment
Wang, Y (2004)79 China | 111 | % male: 64.1% Mean age: NR | Diagnosed third lumbar vertebra transverse process syndrome | 1. Waiguan-through-Neiguan and Lumbus 2 through-Lumbus 4 and transverse acupuncture methods, n = 66; 2. routine acupuncture, n = 45; Treatment provider: NR | 1 treatment/day 10 treatments/course | 1. Quality of Life: well being,; 2. ADVERSE EVENTS: no harms reported; Data measured at end of treatment | 2/13
Zhou, Z (2004)80 China | 82 | % male: 63.3% Mean age: NR | LBP or sciatic nerve pain, pain may become worse when coughing, sneezing or bow movement; pain on lumbar vertebra or sciatic nerve, test of raising straight leg; CT or MRI examination diagnostic lumbar intervertebral disc protrusion | 1. abdominal acupuncture + Danshen injection + TDP illuminate, n = 42; 2. lumbar shallow acupuncture + Danshen injection + TDP illuminate, n = 40; Treatment provider: NR | 1 treatment/day 4 courses 24 days, 1 day between courses Injection: 1 treatment/day 20 days | 1. Quality of Life: well being, Chinese Medical Diagnostic and therapeutic Standard; 2. ADVERSE EVENTS: no harms reported; Data measured at 20 or 24 days | 4/13
Chu, J (2004)81 China | 50 | % male: 58% Mean age: 42.5 yrs | Chinese Medical Diagnostic and Therapeutic Standard. | 1. scalp acupuncture + massage, n = 25; 2. massage, n = 25; Treatment provider: NR | 1 treatment/day, 10 treatments/course, 2 courses 20 days | 1. Quality of Life: well being, Chinese Medical Diagnostic and therapeutic Standard; 2. ADVERSE EVENTS: no harms reported | 4/13
Wu, Y (2004)82 China | 114 | % male: 60.3% Mean age: NR | Diagnosed using Chinese Medical Diagnostic and Therapeutic Standard | 1. abdominal acupuncture, n = 62; 2. body acupuncture, n = 52; Treatment provider: NR | 1 treatment/day, 10 treatments/course, 3 courses 30 days | 1. Quality of Life: well being; 2. ADVERSE EVENTS: no harms reported; Data measured at 30 days | 3/13
Zhu, Q (2003)83 China | | % male: 80% Mean age: 33.5 yrs | Diagnosed using Chinese Medical Diagnostic and Therapeutic Standard | 1. acupuncture + Moxibustion + autonomic traction of knee-chest, n = 31; 2. acupuncture + Moxibustion, n = 29; Treatment provider: NR | 30 treatments total 30 days | 1. Quality of Life: well being; 2. Pain: VAS; 3. ADVERSE EVENTS: no harms reported; Data measured at 30 days | 4/13
Zhang, Honglai (2003)84 China | 120 | % male: 54.2 Mean age: NR | diagnosed as Cervical Spondylosis using ref[1] 1993-chinese; compliant with treatment; responded to the surveys | 1. electro-acupuncture, n = 60; 2. traction, n = 60; Treatment provider: NR | 45 treatments total 45 days | 1. Quality of Life: well being; 2. ADVERSE EVENTS: no harms reported; Data measured at 45 days | 6/13
Zhou, Q (1998)85 China | 58 | % male: NR Mean age: 48 yrs | CT diagnosed as lumbar intervertebral disc protrusion | 1. acupuncture on Jiaji, n = 30; 2. acupuncture on pangguangjingxue, n = 28; Treatment provider: NR | 30 treatments total 30 days | 1. Quality of Life: well being; 2. ADVERSE EVENTS: no harms reported; Data measured at 30 days | 3/13
Xia, F (1997)86 China | 82 | % male: NR Mean age: NR | X-ray or CT diagnosed Mixed | 1. acupuncture + injection + massage, n = 41; 2. acupuncture, n = 40; Treatment provider: NR | 1 treatment/2 days 10 treatments/course | 1. Quality of Life: well being; 2. ADVERSE EVENTS: no harms reported; Data measured at end of treatment | 2/13
Li, Q (1997)87 China | 156 | % male: 51.3 Mean age: NR | NR | 1. acupuncture + cupping, n = 78; 2. acupuncture, n = 78; Treatment provider: NR | 1-2 treatment/day, 10 treatments/course Cupping-1 treatment/2days Until cured | 1. Quality of Life: well being; 2. ADVERSE EVENTS: no harms reported; Data measured at end of treatment | 2/13
Ding, Y (1998)88 China | 54 | % male: 71.6 Mean age: 43.5 yrs | LBP repeatedly occurring; lumbar sacrum pain become worse with fatigue; X-ray and examination exclude the other disease; LBP caused by Qi and blood stagnant. | 1. fly-probing-acupoint manipulation, n = 35; 2. routine acupuncture, n = 19; Treatment provider: NR | 1 treatment/day 10 treatment/course | 1. Quality of Life: well being; 2. ADVERSE EVENTS: no harms reported; Data measured at end of treatment | 3/13
Luo, S (2007)89 China | 108 | % male: 72.2 Mean age: NR | Varying degrees of LBP radiating to the lower limb. With straight leg raising test: </= 30 degrees in 37 cases, 31 - 65 in 68 cases, sand 3 cases with positive response in the intensive test; Patients diagnosed with CT and or MRI exam. | 1. scalp acupuncture + traction, n = 56; 2. traction, n = 52; Treatment provider: NR | 30 min/session 3 sessions | 1. Quality of Life: clinically cured; marked effective; improved; no change; 2. ADVERSE EVENTS: no harms reported; Data measured at 3 sessions
Peng, Y (2006)90 China | 116 | % male: 53.4 Mean age: 47 yrs | Diagnosed using Chinese Medical Diagnostic and Therapeutic Standard; 30-60 yrs; CT-MRI examined and diagnosed; signed on the consent form | 1. acupuncture: round sharp needle therapy combined with massage by a doctor, n = 58; 2. acupuncture : filiform needle plus massage by a doctor, n = 58 | 20 treatments total 20 days | 1. Quality of Life: well being, Chinese Medical Diagnostic and Therapeutic Standard; 2. ADVERSE EVENTS: no harms reported; Data measured at 20 days | 3/13
Zhou, Y (2005)91 China | 242 | % male: 53.1 Mean age: 45.5 yrs | Diagnosed using Chinese Medical Diagnostic and Therapeutic Standard and 1988 Clinical Trial Diagnostic Standard; 20-65 yrs; signed consent form | 1. acupuncture- Huaisanzhen, n = 96; 2. medication-drug control, n = 48; 3. acupuncture, n = 48; 4. combination, n = 50; Treatment provider: NR | NR | 1. Pain: VAS; 2. Quality of Life: well being, Chinese Medical Diagnostic and Therapeutic Standard and 1988 Clinical Trial Diagnostic Standard; 3. ADVERSE EVENTS: no harms reported; Data measured at 1, 12, 24, and 48 hours later | 4/13

Table 1.6 Low Back Pain - Acupuncture - Mixed - Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Zhang, Y (2007)92 China | 120 | % male: 54.17% Mean age: 39.28 yrs | Low back pain | 1. electro-acupuncture, n = 40; 2. acupoint injection of Danggui, n = 40; 3. acupoint injection of O_3_, n = 40; Treatment provider: NR | 10 days total | 1. Pain: Overall efficiency; 2. ADVERSE EVENTS: no harms reported; Data measured at immediate post-treatment | 4/13
Ratcliffe, J (2006)93 (9010) | 241 | % male: 22.5 Mean age: 43.6 years | Adults aged 18-65 with N-S LBP of 4-52 weeks duration | 1. Acupuncture, by acupuncturists trained in traditional Chinese medicine, n = 160; 2. Usual care, n = 81 | 10 treatments 3 months | 1. Pain: bodily pain dimension on SF-36; 2. Quality of Life: QALYs (quality adjusted life years); 3. Cost: NHS; Data measures at 12 and 24 months
Tsukayama, H (2002)94 Japan | 19 | % male: 15.5% Mean age: 45 yrs | LBP without sciatica, at least 2 weeks history of pain and > 20 yrs of age | 1. electro-acupuncture, n = 9; 2. TENS, n = 10; Treatment provider: NR | 2 weeks | 1. Pain: PRS – 10 mm VAS; 2. Disability: JOA; 3. ADVERSE EVENTS: transient aggravation of LBP, n = 2; one of each: discomfort due to needles; pain on needle insertion; small subcutaneous bleeding; transient fatigue; itching with electrode; Data measured at 2 weeks | 7/13
Sakai, T (2001)95 Japan | 68 | % male: 55% Mean age: 36.8 yrs | LBP without sciatica; at least 2-week history of LBP; over 20 years old | 1. electro-acupuncture, n = 32; 2. TENS, n = 36; Treatment provider: NR | 4 treatment sessions total 2 weeks | 1. Pain: pain relief scale- VAS 1-10 cm; 2. Disability: JOA score; 3. ADVERSE EVENTS: n = 2, itching with electrode and dullness after treatment; Data measured at 2 weeks | 8/13
He (1997)96 China | 100 | % male: NR Mean age: 44 yrs | LBP, fixed in location, limited range of motion, worse in cold and raining weather. | 1. manual acupuncture + Moxibustion + Chinese herbal medicine, n = 50; 2. Chinese herbal medicine, n = 50; Treatment provider: NR | Total of 20 treatments 20 days | 1. Quality of Life: cured-treatment effect; marked effective; improved; no change; 2. ADVERSE EVENTS: no harms reported; Data measured at 20 days and 1 year | 4/13
Thomas, KJ (2006)97 UK | 241 | % male: 40.5% Mean age: 43 yrs | Patients aged 18-65 yrs with non-specific LBP of 4-52 weeks duration, assessed as suitable by their general practitioner (GP) for primary care management | 1. acupuncture by 6 acupuncturists with 3.2 yrs mean duration of training and mean of 12.8 yrs in practice, n = 160; 2. standard treatment-usual care, n = 81 | 10 treatments 3 months | 1. Pain: SF-36 Bodily Pain score; McGill PPI; 2. Disability: Oswestry Disability Index; 3. Quality of Life: SF-6D; 4. ADVERSE EVENTS: no harms reported; Data measured at 3, 12 and 24 mo | 9/13

Table 1.7 Low Back Pain - Acupuncture - Unknown - Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Wang, Z (2009)98 China | 139 | % male: 67.5% Mean age: 58.9 yrs | Patients with senile radical sciatica | 1. electro-acupuncture, n = 70; 2. TENS, n = 69; Treatment provider: NR | 2 courses (possibly 5-7 days in each course) | 1. Quality of Life: cure rate (%); 2. ADVERSE EVENTS: no harms reported; Data measured at end of each course
Wu, J (2004)99 China | 300 | % male: NR Mean age: NR | Diagnosed as lumbar intervertebral disc protrusion; 25-60 yrs; stop using other treatment or medicine; signed consent form | 1. electro-acupuncture by professional doctor, n = 100; 2. normal acupuncture by same doctor, n = 100; 3. medicine by same doctor, n = 100 | 1 treatment/day, 10 treatments/course, 2 courses 20 days | 1. Quality of Life: well being, using both Chinese and Western diagnostic and therapeutic standard for Lumbar intervertebral disc protrusion; 2. ADVERSE EVENTS: no harms reported; Data measured at 20 days | 4/13
Lee, J (2007)100 Korea | 31 | % male: 0 Mean age: NR | Female patients 20-50 yrs old with LBP and accompanied sciatic neuralgia | 1. Kuesu-point acupuncture, n = 16; 2. non Kuesu-point acupuncture, n = 15; Treatment provider: NR | 12-15 sessions 3 weeks | 1. Pain: VAS 0-10; 2. Quality of Life: Estimation Index of Backache 0-100; 3. ADVERSE EVENTS: no harms reported; Data measured at 3 weeks | 3/13

Table 1.8 Low Back Pain - Acupuncture - Unknown - Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Garvey, TA (1989)101 US | 63 | % male: 65.1% Mean age: 38 yrs | Patients treated for strain LBP with non-steroidal anti-inflammatory agents; hot showers; avoidance activity that might aggravate the pain for 4 weeks | 1. Trigger point (TP) method I: Lidocaine injection- and method II: Lidocaine and Aristospan injection, n = 27; 2. dry-needling injection, n = 20; 3. ethylchoride spray, n = 16; Treatment provider: NR | One time intervention | 1. Pain: self rating scale (1-10); pain improvement; 2. ADVERSE EVENTS: no harms reported; Data measured at 2 weeks | 7/13
Mencke (1988)102 Germany | 75 | % male: 49.3% Mean age: 49.4 yrs | Patients who have previously been treated unsuccessfully (general practitioner, orthopedic, physiotherapist); no involvement in other therapies | 1. typical AP by same therapist, n = 40; 2. atypical AP by same therapist, n = 35 | 6 treatment sessions 3 weeks | 1. Pain: VAS average; 2. Disability: Examination of affected arm, orthopaedic parameter, ante version of head; 3. Physical measures: Aversion of the head (AOH); Inner rotation of damages arm (IRDA); 4. ADVERSE EVENTS: no harms reported; Data measured at 3 and 8 weeks | 9/13
Inoue, M (2001)103 Japan | 16 | % male: NR Mean age: 55.7 yrs | Patients with lumbago who attended the university acupuncture clinic as outpatient and gave consent to attend to the trial | 1. acupuncture-real needling by acupuncturist, n = 10; 2. placebo-sham needling by same therapist, n = 6 | Single treatment | 1. Pain: VAS (100 mm) of pain at most restricted action; 2. ADVERSE EVENTS: no harms reported; Data measured post treatment | 10/13
Kurosu, Y (1979)104 A Japan | 20 | % male: 50% Mean age: NR | Patients with pain in the low back or the low back and sacral region. | 1. acupuncture, n = 10; 2. acupuncture-garlic Moxibustion, n = 10; Treatment provider: NR | NR | 1. Pain: pain recovery score by questionnaire; 2. ADVERSE EVENTS: no harms reported; Data measured at 2^nd^ and 4^th^ visit before treatment | 3/13
Kurosu, Y (1979)104 B Japan | 20 | % male: 55% Mean age: NR | Patients with pain in the low back or the low back and sacral region. | 1. acupuncture-needle retention technique, n = 10; 2. acupuncture-simple insertion technique, n = 10; Treatment provider: NR | NR | 1. Pain: pain recovery score by questionnaire; 2. ADVERSE EVENTS: no harms reported; Data measured at 2nd and 4th visit before treatment | 3/13
Edelist, G (1976)105 Canada | 30 | % male: NR Mean age: NR | Patients with disc disease- not responding to conventional therapy including bed rest, analgesics, heat, and physiotherapy | 1. acupuncture, n = 15; 2. sham acupuncture, n = 15; Treatment provider: NR | 3 treatments total, 2 day intervals 6 days | 1. Pain: subjective improvement of pain; 2. ADVERSE EVENTS: no harms reported; Data measured at end of treatment | 2/13
Kawase, Y (2006)106 Japan | 64 | % male: 56% Mean age: 52.8 yrs | NR | 1. whole body acupuncture pole treatment (Taikyo-Ryoho) + low frequency acupuncture by acupuncturist with 6-53 yrs experience, n = 12; 2. whole body acupuncture pole treatment by same therapist, n = 13; 3. low frequency acupuncture by same therapist, n = 20; 4. sham acupuncture by same therapist, n = 19 | 1 time treatment | 1. Pain: therapeutic effectiveness-VAS; 2. Disability: measuring patients’ ADL-JOA score; 3. ADVERSE EVENTS: no harms reported; Data measured at end of single treatment | 10/13

Table 1.9 Low Back Pain - Manipulation – Acute/Sub-acute - Specific Pain – No Studies

Table 1.10 Low Back Pain – Manipulation – Acute/Sub-acute - Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Russell I (UK BEAM Trial) (2004)107 UK | 1334 | % male: 43.2 Mean age: 43.1 yrs | Patients aged 18-65 yrs with LBP (RMDQ => 4) who had experienced the pain daily for the past month | 1. standard care by general practitioner (GP), n = 338; 2. Exercise by trained Physical therapists with ≥ 2 yrs experience, n = 310; 3. Private-M by qualified manipulators, n = 180; 4. NHS-M by same therapists/manipulators, n = 173; 5. Private-M + Exercise by same therapists/manipulators , n = 172; 6. NHS-M + Exercise by same therapists/manipulators, n = 161 | 8 sessions over 4-8 weeks Last session at 12 weeks | 1. Pain: Serious spinal disorder; 2. ADVERSE EVENTS: no harms reported; Data measured at 12 weeks | 5/13
Hoiriis K (2004)108 | 156 | % male: 56.7 Mean age: 41.9 yrs | 21 - 59 years old with uncomplicated LBP of 2 - 6 weeks duration | 1. Chiropractic adjustments and medical placebo by a chiropractor, medical doctor, n = 50; 2. Muscle relaxants and sham adjustments by a medical doctor, n = 53; 3. Medical placebo and sham adjustments by a medical doctor, n = 53 | N of treatments varied 7 weeks | 1. Pain: VAS (10 cm); 2. Disability: Oswestry LBP Disability Questionnaire; 3. ADVERSE EVENTS: no harms reported; Data measured at 7 weeks and 3 mo | 8/13
Hsieh, C (2002)109 California | 200 | % male: 65.4 Mean age: 48.2 yrs | 18 years or older, LBP between 3 weeks and 6 months for the current episode or a pain-free period of at least 2 months in the preceding 8 months for recurrent LBP, agreement for randomization, and consent for treatment | 1. Back school program by experienced licensed physical therapists and chiropractors, n = 48; 2. Myofascial therapy program by trained clinicians – Physical therapists and chiropractors, n = 51; 3. Joint manipulation by experienced licensed chiropractors with 5 years min. Clinical experience, n = 49; 4. Combined joint manipulation + myofascial therapy, same providers as group 2 and 3n = 52 | 1-3 times/week 3 weeks | 1. Pain: VAS scale for pain during past week; 2. Disability: Roland-Morris Activity Scale (RMAS); 3. ADVERSE EVENTS: n = 23 reported adverse effects, mostly transient exacerbations of symptoms; N based on intent to treat Data measured at 3 weeks an 6 mo | 4/13
Seferlis T (2000)110 Stockholm, Sweden | 180 | % male: 53 Mean age: NR | 18 - 16 years of age; LBP with or without sciatica requiring sick- leave; and a sick-leave period for LBP less than 2 weeks before entering the study. Acute | 1. General practitioner program (GPP) (Control), n = 60; 2. Manual Therapy program (MTP), by physiotherapist, n = 60; 3. Intensive Training program (ITP), by physical therapist, n = 60 | 3 times/week 8 weeks only reported for ITP group | 1. Cost: Direct, indirect and total costs; 2. ADVERSE EVENTS: no harms reported | 5/13
Pope, M (1994)111 California, US | 240 | % male: 62 Mean age: 32 yrs | Ages 18-55 years; general good health; LBP between 3 weeks and 6 months duration (this episode); free from LBP for minimum 3 weeks for this episode | 1. Manipulation by 5 licensed chiropractors, n = 60; 2. Soft-tissue massage by 2 licensed massage therapist serving as a chiropractor, n = 30; 3. Transcutaneous muscle stimulation by a licensed chiropractor, n = 30; 4. Lumbosacral corset by a licensed chiropractor, n = 30 | 9 sessions 3 weeks | 1. Pain: 10 cm VAS; 2. Disability: Rage of motion-Schober’s test – Extension; Flexion; 3. ADVERSE EVENTS: no harms reported; Data measured at 3 weeks | 5/13
Sanders GE (1990)112 US | 18 | % male: 50 Mean age: NR | Patients with acute LBP (< 2 weeks) naïve to chiropractic manipulation and had not taken any pain medication for 48 hrs prior to the study enrolment | 1. Spinal manipulation, n = 6; 2. Sham-SM, n = 6; 3. No treatment, n = 6; Treatment provider: NR | One treatment | 1. Pain: VAS; 2. ADVERSE EVENTS: no harms reported; Data measured at end of single treatment | 7/13
Hadler NM (1987)113 US | 54 | % male: 48 Mean age: NR | Patients aged 18-40 yrs with acute LBP (<= 1 mo), no other episode of back pain in previous 6 mo, not work-related pain, no previous surgery | 1. Mobilization by an investigator with experience, n = 28; 2. Manipulation by the same investigator, n = 26 | NR | 1. Disability: RMDQ; 2. ADVERSE EVENTS: no harms reported; Data measured at 3 mo | 7/13
Alaksiev A (1996)114 | 65 | % male: 49.2 Mean age: 33.4 years | Outpatients with LBP lasting no more than 1 mo | 1. SM, n = 22; 2. Relaxation, n = 22; 3. Placebo, n = 21; Treatment provider: NR | 3-4 treatment/week 3 weeks | 1. Total improvement; 2. ADVERSE EVENTS: no harms reported | 3/13
Rasmussen, G (1979)115 | 24 | % male: 100 Mean age: 34.9 years | Male outpatients, 20-50 years of age with LBP without signs of root pressure; duration less than 3 weeks; no treatment except analgesics prior to the trial | 1. Short wave, n = 12; 2. Manipulation in pain free direction by a physiotherapist or physician, n = 12 | 3 times/week-6 sessions 2 weeks | 1. Pain: Restoration; 2. Disability: Schober’s test; 3. ADVERSE EVENTS: no harms reported; Data measured at 2 weeks | 2/13
Shah, M (1989)116 UK | 16 | % male: NR Mean age: NR | Patients with acute back pain | 1. Manipulation, n = 10; 2. Naprosyn (oral medication), n = 6; Treatment provider: NR | 7 days (assumed) | 1. Quality of Life:% improved; 2. Pain: PRS; 3. Disability; 4. ADVERSE EVENTS: no harms reported; Data measured at 1 and 4 weeks

Table 1.11 Low Back Pain- Manipulation- Chronic specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Morton, J (2005)117 | 29 | % male: 35 Mean age: 44.6 yrs | Aged between 18 and 70 years with acute mechanical LBP of approx. 4 weeks or less; Pain located between T12 and the gluteal fold (might radiate to one lower limb) | 1. Manipulation + exercise, n = 15; 2. Exercise alone, n = 14; Treatment provider: NR | 8 treatments total 4 weeks | 1. Pain: AVAS; 2. Disability: RMDQ; 3. ROM in degrees; 4. ADVERSE EVENTS no harms reported; Data measured at 4 weeks | 4/13
Hoehler, FK (1981)118 USA | 95 | % male: 59.0 Mean age: 31 years | Patients with low back pain candidate for manipulation by palpatory cues; no psychosocial or contradictions for manipulation | 1. Manipulation by a physician, n = 56; 2. Soft tissue massage by the same physician, n = 39 | 1 treatment session | 1. Pain: VAS; 2. Range of motion; 3. Adverse events: not reported | 3/13
Postacchini, F (1988)119 Italy | 398 | % male: 50.5 Mean age: 36.5 ****– 39.5 years | Low back pain patients aged 17-58 years presenting at 2 clinics | 1. Manipulation by a trained chiropractor, n = 87; 2. Drug therapy, n = 81; 3. Physiotherapy, n = 78; 4. Bed rest, n = 29; 5. Low back school, n = 50; 6. Placebo, n = 73 | 7 times for 1^st^week, then twice for up to 6 weeks | 1. Combined Score (Pain VAS, disability, forward spinal flexion, leg lowering test) on a 32 point scale ranging from 5 (poor clinical status) to 32 (excellent clinical status). | 6/13

Table 1.12 Low Back Pain – Manipulation - Chronic - Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Haas, M (2004)120 NR | 191 | % male: 45.8 Mean age: 47.8 yrs | Current episode of CLBP; LB was defined as the area below the 12^th^ rib and above the gluteal fold. Chronic defined as episode of pain of at least 3 months duration; 18 yrs or older; English literacy | 1. a- 3 treatments of spinal manipulation (SM); b- a + 3 treatments of physical modalities (PM) by 4 chiropractors with 2-22 yrs of practice experience, n = 54; 2. a- 6 treatments of SM; b- a + 6 treatments of PM by same the chiropractors, n = 46; 3. a- 9 treatments of SM; b- a + 9 treatments of PM by same the chiropractors, n = 44; 4. a-12 treatments of SM; b- a + 12 treatments of PM by the same chiropractors , n = 47 | 3-12 treatments total 3 weeks | 1. Pain: Von Korff Pain Scale; 2. Disability: Von Korff Disability Scale; 3. ADVERSE EVENTS: no harms reported; Data measured at 3 and 12 weeks | 7/13
Niemisto (2003)121 | 204 | % male: 46 Mean age: 37 yrs | 24-46 yrs, employed, patients who had LBP (with or without sciatica) of at least 3 months’; self- rated disability index (Oswestry LBP Disability Questionnaire) score had to be at least 16% Chronic | 1. Manipulation + Stabilizing exercise, by experienced manual therapist, n = 102; 2. Consultation only, by physician, n = 102 | 4 treatments 4 weeks | 1. Pain: VAS (0-100); PDI (6 pts); RMQ adjusted for length of symptoms; VAS (100 mm); 2. Disability: ODI (0-100); 3. Quality of Life:; 4. Work: N days of work, sick leaves; 5. Utility of conventional care: Visits to physicians; visits to physiotherapy; 6. Cost: total healthcare cost; 7. ADVERSE EVENTS: no harms reported; Data measured at 5 and 12 mo | 8/13
Triano JJ (1995)122 US | 209 | % male: 54 Mean age: 41.6 yrs | Patients aged => 18 yrs with mechanic CLBP (pain > 12 months between L1 and L5 including sacroiliac joints) experiencing palpatory tenderness | 1. SM (HVLA), n = NR; 2. HVLF mimic, n = NR; 3. BEP, n = NR; Treatment provider: NR | Daily sessions 2 weeks | 1. Pain: VAS; 2. Disability: Oswestry scale; 3. ADVERSE EVENTS: no harms reported; Data measured at 2 weeks and 3 mo | 6/13
Cote P (1994)123 Canada | 30 | % male: 54.4 Mean age: 31 yrs | Patients with mechanic CLBP > 2 mo | 1. Manipulation by a clinician, n = 16; 2. Mobilization by a clinician, n = 14 | One session | 1. Pain: PPT-L5 tender point; SI ligament tender point; gluteus tender point; 2. ADVERSE EVENTS: no harms reported; Data measured at end of single session | 4/13
Mohseni-Bandpei, M (2006)124 UK | 120 | % male: 41% Mean age: 36 yrs | Patients with CLBP, age 18-55 with pain in LB between L1 and L5 and the sacroiliac joints; had LBP > 3 mo, signs and symptoms interpreted to be referred from the lumbar spine and not other organs; good self-reported general health | 1. Manipulation/Exercise by one qualified manipulative therapist, n = 60; 2. Ultrasound/exercise by a second physiotherapist, n = 60 | 6 sessions 1-2 times/week | 1. Pain: VAS pain intensity; 2. Disability: Oswestry Disability Index (%); 3. ADVERSE EVENTS: no harms reported; Data measured at end of treatment 3 or 6 weeks | 2/13
Biedermann, F (1980)125 NR | NR | % male: NR Mean age: 30.5 yrs | Sudden onset associated with trauma, recent onset usually of 2 or 3 weeks duration, abnormally low straight leg raising tests presumably due to tight hamstrings | 1. Rotational Manipulation, n = NR; 2. Soft-tissue Massage, n = NR; Treatment provider: NR | NR | 1. Pain: duration of pain relief (mean in days); 2. ADVERSE EVENTS: no harms reported; Data measured at 3 mo | 3/13
Waagen, G (1986)126 Iowa, US | 29 | % male: 46.7 Mean age: 24.8 yrs | Chief complaint of LBP; no experience with chiropractic | 1. Spinal adjusting therapy by a chiropractor, n = 11; 2. Sham adjustment by a chiropractor, n = 18 | 2-3 treatments/week 2 weeks | 1. Pain: 10 cm VAS decrease; 2. Disability: Straight leg raising test; Lumbar flexion; Lumbar extension; Global index; Lateral flexion; 3. ADVERSE EVENTS: no harms reported; Data measured at 2 weeks and 3 mo | 5/13
Rasmussen, J (2008)127 Denmark | 72 | % male: Mean age: | 18-60 yrs; LBP more than 3 mo | 1. Extension exercises + Manipulation by and examiner with a diploma in manual medicine, n = 35; 2. Extension exercises by the same examiner, n = 37 | Manipulation at baseline, 2 and 4 weeks | 1. Pain: VAS (1-10); 2. ADVERSE EVENTS: reported but no details; Data measured at 3 and 6 mo | 6/13
Lalanne, K (2009)128 Quebec | 27 | % male: 52.2 Mean age: 39.8 yrs | 18-60 yrs; constant or recurrent LBP for more than 6 mo Chronic | 1. Lumbar Spine Manipulation by an experienced chiropractor, n = 13; 2. Control (no manipulation-side lying posture), n = 14 | One manipulation | 1. Pain: VAS (1-100); 2. ADVERSE EVENTS: no harms reported; Data measured after end of treatment | 1/13
Giles, LGF (1999)129 Australia | 69 | % male: 35.67% Mean age: 41.3% | Patients suffering from spinal pain for at least 13 weeks; at least 18 years of age | 1. acupuncture, n = 18; 2. Spinal manipulation, n = 32; 3. medication, n = 19; Treatment provider: NR | 6 treatments 3-4 weeks | 1. Pain: VAS; 2. Disability: Oswestry Disability Index; 3. ADVERSE EVENTS: no harms reported; Data measured at 3-4 weeks | 1/13
Giles, LG (2003)17 Australia | 115 | % male: 54.93% Mean age: 26.1 yrs | Patients at least 17 yrs; uncomplicated mechanical spinal pain for 13 weeks minimum-for long-term fu > 1 yr; those who received their randomly allocated treatment regimen during treatment period | 1. acupuncture (LB, NP, thorax), n = 36; 2. spinal manipulation, n = 36; 3. medication that has not been tried by Patients in this group, n = 43 | Maximum of 9 weeks | 1. Pain: pain frequency; VAS intensity; 2. Disability: Oswestry Disability; 3. Quality of Life: SF-36; 4. ADVERSE EVENTS: hematoma and bleeding, n = 1 committed suicide; Data measured at 9 weeks and 1 yr | 6/13
Postacchini, F (1988)119 Italy | 398 | % male: 50.1% Mean age: 36.3 – 40.3 | Patients 18 – 58 years Group I: LBP with no radiating pain, n = 271 Acute, chronic, or acute with chronic history Group II: LBP with radiating pain, n = 188 Acute and chronic | 1. spinal manipulation by trained chiropractor, n = 271; 2. drug therapy: NSAIDS (Diclofenac); 3. physiotherapy: light massage, analgesic currents and diathermy (infrareds in acute syndromes and short wave diathermy in chronic); 4. placebo: antioedema gel contained in a vessel without identification; 5. bed rest; 6. low back school (only in chronic syndromes) based on Canadian model of back education | 3 (acute), to 6 (chronic) weeks | 1 pain severity, VAS 1 – 4 (higher better); 2 disability: patients ability to perform ten everyday activities as assessed by a disability questionnaire (1 -= extremely disabled; 4 = unlimited); 3 forward flexion, (fingertips and floor distance: > 60 cm = 1 pint; < 20 cm = 4 pints); 3 abdominal muscle strength by leg lowering test; 4 isometric endurance of back muscles | 6/13
Herzog, W (1991)130 Canada | 37 | % male: 67.6% Mean age: 33.5 years | Patients age 18- 50 years, ambulatory with chronic sacroiliac joint problems diagnosed independently by two chiropractors | 1. spinal manipulation, by chiropractors, n = 16; 2. back school therapy by physiotherapist, n = 13 | 4 weeks, 10 treatments | 1. pain intensity by VAS (recovery = 0 on scale of 0 – 10); 2. disability, by Oswestry Functional Disability questionnaire (recovery = 6% or less); 3. sacroiliac joint fixation evaluation by Gillett motion palpation test; 4. gain analysis by Kistler force platform; 5. Adverse events: NR | 5/13

Table 1.13 Low Back Pain – Manipulation – Mixed - Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Jull, G (2005)131 Australia | 200 | % male: NR Mean age: 36.6 years | Patients between 18-60 years with chronic cervicogenic headaches | 1. Manipulative therapy, n = 51; 2. Therapeutic exercise, n = 52; 3. Combined exercise and manipulative therapy, n = 49; 4. Control, n = 48; Treatment provider NR | 6 weeks | 1. Pain: VAS (10 cm); PRI; MPQ; 2. Disability – Northwick Park Neck Pain Questionnaire; CCFT (25); Data measured at 7 weeks and 3, 6, and 12 months post intervention
Mathews W (1988)132 | 282 | % male: NR Mean age: NR | 18-60 years of age; presenting episode of pain of less than 3 mo | 1. Manipulation, Trial B1, n = 31; 2. Control-Infrared lamp, Trial B1, n = 25; 3. Manipulation, Trial B2, n = 127; 4. Control-Infrared lamp, Trial B2, n = 99; Treatment provider: NR | 3 times/week 2-3 weeks | 1. Pain: VAS (1-6); 2. ADVERSE EVENTS: no harms reported; Point of measurement not reported | 2/13
Zhang, W (2008)133 China | 11928 | % male: NR Mean age: NR | Diagnosed using Chinese Medical Diagnostic and therapeutic Effective Standard; diagnosed using CT or MRT; signed consent form | 1. Manipulation reduction + lumbar traction + various physiotherapies, n = 5760; 2. Lumbar traction + various physiotherapies, n = 5368; Treatment provider: NR | 30 treatments 30 days | 1. Pain: VAS; 2. Quality of Life: well being, NR; 3. ADVERSE EVENTS: no harms reported; Data measured at 30 days | 4/13

Table 1.14 Low Back Pain - Manipulation - Mixed - Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Childs, JD (2004)134 US | 131 | % male: 58 Mean age: 34 yrs | LBP Patients aged 18-60 yrs with ODQ score ≥ 30% | 1. SM + exercise by 13 licensed Physical therapists who received one training session, n = 70; 2. Exercise by same therapists, n = 61 | 4 weeks | 1. Disability: ODQ; 2. Utility of conventional care: medication use; healthcare utilization; 3. ADVERSE EVENTS: no harms reported; Data measured at 4 weeks and 6 mo | 8/13
UK BEAM Trial (2004)135 UK | 1334 | % male: NR Mean age: NR | Mixed | 1. General practice, n = 326; 2. Exercise program, n = 297; 3. Spinal manipulation, n = 342; 4. Combined treatment, n = 322 | 2 9 classes; 3 8 sessions; 4 6 weeks manipulation + 6 weeks exercise; 12 weeks | 1. Cost: healthcare; cost/QALYs; 2. Quality of Life: QALYs | 2/13
Cherkin D (2008)136 Ottawa, Canada | 321 | % male: 52.7 Mean age: 40.5 yrs | 20-64 years old who saw their primary care physician for LBP and who still had pain seven days later. | 1. Physical Therapy by 13 therapists with a median of 14 yrs experience, n = 133; 2. Chiropractic Manipulation by chiropractors with 6-14 yrs experience, n = 122; 3. Educational Booklet, n = 66 | Up to 9 visits 1 mo | 1. Quality of Life: Bothersomeness of symptoms index; 2. Disability: RDQ; 3. ADVERSE EVENTS: no harms reported; Data measured at 1 and 3 mo | 5/13
Hoehler F (1981)137 California | 95 | % male: 59 Mean age: 31.1 yrs | Presence of palpatory cues indicating that manipulation might be successful | 1. Rotational Manipulation of lumbosacral spine by a physician, n = 56; 2. Soft-tissue massage by a physician, n = 39 | N of treatments varied | 1. Pain: Improvement in amount of pain; 2. ADVERSE EVENTS: no harms reported; Data measured at end of treatment | 3/13
Mathews W (1988)132 | 282 | % male: NR Mean age: NR | 18-60 years of age; presenting episode of pain of less than 3 mo | 1. Manipulation, Trial B1, n = 31; 2. Control-Infrared lamp, Trial B1, n = 25; 3. Manipulation, Trial B2, n = 127; 4. Control-Infrared lamp, Trial B2, n = 99; Treatment provider: NR | 3 times/week 2-3 weeks | 1. Pain: VAS (1-6); 2. ADVERSE EVENTS: no harms reported; Point of measurement not reported | 2/13
Bronfort, G (1989)138 Denmark | 19 | % male: 49 Mean age: 37.5 yrs | Native to chiropractic and between 18-70 yrs of age; Primarily suffering from LBP of various durations with or without radiating pain to one or both lower extremities | 1. Chiropractic-no practical technique named by chiropractors, n = 10; 2. Medical-analgesic, local analgesic- anaesthetic injections, bed rest and/or physiotherapy by MDs, n = 9 | 1 month | 1. Pain: Patient rate of improvement; 2. ADVERSE EVENTS: no harms reported; Data measured at 1, 3, and 6 months | 2/13
Rupert R (1985)139 Egypt | 145 | % male: NR Mean age: NR | 18-68 years with LBP or leg pain and/or restriction in lumbar ROM | 1. SM by 2 clinically experienced chiropractors, n = 49; 2. Sham SM by same chiropractors, n = 46; 3. Medication, Drugs and bed rest by a team of medical orthopaedic specialists, n = 50 | 3 treatment/week | 1. Pain reduction | 2/13
Zhang, W (2008)133 China | 11928 | % male: NR Mean age: NR | Diagnosed using Chinese Medical Diagnostic and therapeutic Effective Standard; diagnosed using CT or MRT; signed consent form | 1. Manipulation reduction + lumbar traction + various physiotherapies, n = 5760; 2. Lumbar traction + various physiotherapies, n = 5368; Treatment provider: NR | 30 treatments 30 days | 1. Pain: VAS; 2. Quality of Life: well being, NR; 3. ADVERSE EVENTS: no harms reported; Data measured at 30 days | 4/13
Hoiriis K (1999)140 | 26 | % male: NR Mean age: NR | LBP of greater than 2 months | 1. Cervical adjustments, n = NR; 2. Full Spine Adjustments, n = NR; 3. Combination of both techniques, n = NR; Treatment provider: NR | Up to 6 mo | 1. Pain: VAS; 2. Disability: Oswestry Disability Questionnaire; 3. ADVERSE EVENTS: no harms reported; Data measured at 6 mo | 0/13
Herzog, W (1991)130 Canada | 29 | % male: 76.5 Median age: 33.5 years | Patients with chronic sacroiliac joint problem, aged 18-50 years, ambulatory | 1. Manipulation by a chiropractor, n = 16; 2. Other (stretching, exercises) by a physiotherapist, n = 13 | 10 sessions over 4 weeks | 1. Pain (VAS); 2. Functional disability (Oswestry); 3. Harms (not reported)
Evans, D.P (1978)141 | 32 | % male: 47 Mean age: NR | Patients with chronic LBP | 1. Rotational manipulation, n = 15; 2. Control, n = 17; Treatment provider NR | 3 treatments at weekly intervals | 1. Anterior spinal flexion measurements; 2. Pain: daily pain scores; 3. Patients global assessment; 4. Patients assessment of efficacy; Data measured at 21 and 42 days
Honduras, M (2009)142 | 240 | % male: 56 Mean age: 63.1 years | Subjects at least 55 years old with sub-acute or chronic non-ridiculer LBP | 1. High velocity, low amplitude spinal manipulation, by 4 chiropractors with more than 6 yrs experience, n = 96; 2. Low velocity, variable amplitude spinal mobilization, by same treatment providers as group 1, n = 95; 3. Minimal conservative medical care, n = 49 | 12 visits of HVLA-SM, LVVA-SM or 3 visits of MCMC 6 weeks | 1. Disability: 24-item Roland Morris disability questionnaire; 2. Pain: severity of pain-100 mm VAS; 3. Global improvement measure; Data measured at 3, 6, 12, and 24 weeks

Table 1.15 Low Back Pain - Manipulation - Unknown - Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Dai, DC (2006)143 China | 99 | % male: 23.2 Mean age: 58.1 yrs | Lumbar stability of degenerative spondylolisthesis | 1. Spinal fine adjusting manipulation, n = 50; 2. Flexing hip and knee manipulation, n = 49; Treatment provider: NR | 10 treatments 5 weeks | 1. Pain: Local standard of integrated score of symptoms and function; 2. Disability: X-ray changes of lumbar spine; 3. ADVERSE EVENTS: no harms reported; Data measured at 5 weeks | 3/13

Table 1.16 Low Back Pain – Manipulation - Unknown - Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Shearar K (2004)144 South Africa | 60 | % male: 50 Mean age: NR | 18 - 59 ; diagnosed with sacroiliac joint syndrome | 1. High velocity, Low amplitude chiropractic adjustments (HVLA) by a chiropractor, n = 30; 2. Mechanical force, manually assisted chiropractic adjustments by the same chiropractor, n = 30 | 4 treatments 2 weeks | 1. Pain: NRS-101; 2. Disability: Revised Oswestry LBP Disability Questionnaire; 3. ADVERSE EVENTS: no harms reported; Data measured at 2 weeks | 1/13

Table 1.17 Low Back Pain – Mobilization – Acute/Sub-acute-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Hadler NM (1987)113 US | 54 | % male: 48 Mean age: NR | Patients aged 18-40 yrs with acute LBP (<= 1 mo), no other episode of back pain in previous 6 mo, not workrelated pain, no previous surgery | 1. Mobilization by an investigator with experience, n = 28; 2. Manipulation by the same investigator with experience, n = 26 | NR | 1. Disability: RMDQ; 2. ADVERSE EVENTS: no harms reported; Data measured at 3 mo | 7/13
Hanrahan, S (2005)145 U.S. | 19 | % male: 100 Mean age: 20.3 years | Male collegiate athletes with acute low back pain and no neurological deficits or suspected disc herniation | 1. Grade 1 (small amplitude) or 2 (large amplitude) posteroanterior joint mobilization by a certified athletic trainer, n = 9; 2. Control, n = 10; Co-intervention: standardized protocol of cryotherapy and stretching | Single session | 1. Pain (McGill Pain Questionnaire, and VAS); 2. Muscle strength (by handheld dynamometer); Measured immediately post intervention | 2/13
Aleksiev A (1995)146 Bulgaria | NR | % male: 46.3 Mean age: NR | LBP but not a candidate for surgery prior or during the trial | 1. Post-isometric relaxation, n = NR; 2. AFSMC and sham mobilization, n = NR; 3. Perl’s traction therapy and sham mobilization, n = NR; 4. Sham mobilization, n = NR; Treatment provider: NR | 20 treatment days, 12 procedures each group | 1. Pain:; 2. Disability:; 3. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention and 6 mo | 2/13

Table 1.18 Low Back Pain – Mobilization – Acute/Sub-acute-Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Wreje, U (1992)147 Sweden | 39 | % male: 0 (all female) Mean age: 32 years | Patients with LBP due to pelvic joint dysfunction , and no neurological disease or spine pathology | 1. Spinal mobilization, n = 18; 2. Sham mobilization (manual transverse frictions on the gluteus medius), n = 21; Standardized co-intervention: paracetamol Treatment provider: NR | Single session | 1. Pain (VAS); 2. number of patients using analgesic drugs; Measured immediately after intervention | 4/13

Table 1.19 Low Back Pain – Mobilization – Chronic-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Timm, K. E (1994)148 US | 250 | % male: 73 Mean age: 43 years | LBP with or without radiation, and associated symptoms for at least 6 months following a single-level lumbar laminectomy of the L5 segment | 1. Joint Manipulation by a physical therapist, n= 50; 2. Physiotherapy by the same therapist, n=50; 3. Low-tech McKenzie exercises by the same therapist, n= 50; 4. High-tech Cybex exercises by the same therapist, n= 50; 5. No treatment, n= 50 | Three times per week for 8 weeks | 1. Functional Disability (Oswestry, Schober) (A, B) | 4/13

Table 1.20 Low Back Pain – Mobilization – Chronic-Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Ritavanen, T (2007)149 Finland | 61 | % male: 55 Mean age: 41 years | Patients with chronic LBP aged 20-60 yrs who had restricted functioning and no contradiction to mobilization | 1. Spinal mobilization by experienced bone setter , n = 33; 2. Physiotherapy including massage, therapeutic stretching, trunk stabilization exercise, exercise therapy by a fitness centre specialist, n = 28 | 5 treatments with 2 weeks interval 2 months | 1. Pain (VAS 0 - 100); 2. Disability (Oswestry index 0 – 100); 3. ROM (finger- floor distance), lateral bending); 4. Depression score; 5. ADVERSE EVENTS: no information; Measured at short term follow up (1 month after last intervention) | 5/13
Hemmila H (2002)150 Finland | 114 | % male: NR Mean age: NR | Non-retired people ; BP and no contraindicatio ns to manual therapies Sub-acute | 1. Physiotherapy, n = 34; 2. Bone-setting, by 4 folk healers, n = 45; 3. Exercise, n = 35 | Maximum of 10 treatments 6 weeks | 1. Disability: ODQ; 2. ADVERSE EVENTS: no harms reported; Data measured at 6 weeks, 3 and 6 mo | 8/13
Cote P (1994)123 Canada | 30 | % male: 54.4 Mean age: 31 yrs | Patients with mechanic CLBP > 2 mo | 1. Manipulation by a clinician, n = 16; 2. Mobilization by a clinician, n = 14 | One session | 1. Pain: PPT-L5 tender point; SI ligament tender point; gluteus tender point; 2. ADVERSE EVENTS: no harms reported; Data measured at end of single session | 4/13
Mackawan S (2007)151 Thailand | 67 | % male: 39 Mean age: 38.8 yrs | 20 - 60 years; persistent chronic LBP (more than 12 weeks); no evidence of underlying diseases or anatomical abnormalities | 1. Traditional Thai Massage (TTM) by an experienced physiotherapist, n = 35; 2. Joint Mobilization by the same therapist, n = 32 | One 10 min session | 1. Pain: VAS (10 cm); Substance P levels in saliva (severity of chronic pain); 2. ADVERSE EVENTS: no harms reported; Data measured at end of single session | 5/13
Lopez de, C (2007)152 Spain | 100 | % male: NR Mean age: NR | Patients with non specific chronic low back pain, age 18 – 65 and no lumbar fracture; tumour, rheumatoid disease, or spondylolysis | 1. Spinal mobilization, n = NR; 2. No treatment, n = NR; Treatment provider: NR | Single session | 1. Pain: VAS (100 mm); 2. Function; 3. range of motion; 4. ADVERSE EVENTS: no information | 8/13
Hemmila, H. M (1997)153 Finland | 114 | % male: 57 Mean age: 42 years | Back pain between the shoulders and the buttocks | 1. Bone Setting by 4 folk healers, n= 34; 2. Physiotherapy by aphysiotherapist, n = 45; 3. Home exercises by the same therapist, n = 35 | 1-2 times per week for 6 weeks | 1. Pain: VAS (0-100) Pain during past 3 days; 2. Pain Point Sensitivity; 3. Pressure Pain Threshold | 6/13

Table 1.21 Low Back Pain – Mobilization – Mixed – Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Konstantinou K [crossover] (2007)154 UK | 26 | % male: 57 Mean age: 38.3 years | Patients aged > 18 yrs with or without leg pain with LBP Mixed | 1. Flexion mobilization with movement technique (MWMs), n = 15; 2. Placebo-Flexion MWMs, n = 11 | NR | 1. Pain: VAS; 2. Disability: RMDQ-reported for respondents only; Crossover data | 5/13
Hoving, J (2006)155 Netherlands | 183 | % male: NR Mean age: NR | Non-specific NP for at least 2 weeks Mixed | 1. Mobilization, n = 60; 2. Physical Therapy (PT), n = 59; 3. General Care, n = 64 | 1. 6 sessions; 2. 12 sessions; 3. 3 sessions; 6 weeks for all | 1. Pain: Pain intensity 11-pt scale; 2. Disability: Physical dysfunction 11-pt scale; functional neck; 3. Quality of Life: Global perceived recovery; Data measured at 3, 7, 13, 26 and 52 weeks | 7/13
Chiradejnant A (2003)156 Sydney, Australia | 140 | % male: 51 Mean age: 46.4 yrs | Resting pain of more than 2 on a 0 to 10 pain scale and the treating physiotherapist had to agree that spinal mobilisation treatment was indicated. Mixed | 1. Correct mobilization treatment by physiotherapist, n = 70; 2. Randomly assigned mobilization technique, by physiotherapist, n = 70 | Two 1 min repetitions | 1. Pain: VAS (10 cm); 2. ADVERSE EVENTS: no harms reported; Data measured at end of treatment | 9/13
Goodsell, M (2000)157 Australia | 26 | % male: 51.5 Mean age: 39.2 yrs | Current episode of LBP experienced pain in previous 48 hrs; BP elicited by active lumbar flexion or extension movements Mixed | 1. PA Manual mobilization, by one physiotherapist with a postgraduate qualification in manual therapy, n = 12; 2. Control treatment, n = 14 | NR | 1. Pain: McGill Pain score-Worst pain; Overall %; 2. ADVERSE EVENTS: no harms reported; Data measured at end of treatment | 3/13
Chiradejnant, A (2002)158 Australia | 120 | % male: 59 Mean age: 41.2 yrs | Non-specific LBP Mixed | 1. Posteroanterior (PA) mobilization at most symptomatic spinal level, n = 60; 2. Posteroanterior (PA) mobilization at randomly selected lumbar level, n = 60; Treatment provided by one physiotherapist | Two 1 minute repetition | 1. Pain: NRS 11 pt scale; Global Perceived Effect 11 pt scale; 2. ADVERSE EVENTS: no harms reported; Data measured at end of treatment | 5/13
Powers, CM (2008)159 | 30 | % male: 37 Mean age: 31.2 yrs | 18 to 45 years of age with non-specific LBP; recent onset of LBP (duration of < 3 months) Mix (acute, sub-acute) | 1. Passive segmental mobilization, n = 15; 2. Press up exercise, n = 15; Both treatments administered by a physical therapist with 18 yrs of manual therapy experience and certification as an Orthopaedic Clinical Specialist by the American Board of Physical Therapy Specialties | 1 intervention 10 minutes | 1. Pain: VAS; 2. Disability: Lumbar extension; 3. ADVERSE EVENTS: no harms reported; Data measured at end of single treatment | 4/13

Table 1.22 Low Back Pain – Manipulation + Mobilization – Acute/Sub-acute - Specific Pain- No Trials

Table 1.23 Low Back Pain – Manipulation + Mobilization – Acute/Sub-acute-Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Hancock MJ (2007)160 Australia | 240 | % male: 56 Mean age: 40.3 yrs | Patients with acute LBP (< 6 weeks) in the area between the 12th rib and the buttock crease causing moderate pain and disability | 1. Diclofenac-NSAID by a general practitioner, n = 60; 2. Spinal manipulation by Physical therapists with graduate diploma in manipulative therapy, n = 60; 3. Dicloflenac + SM by a general practitioner and Physical therapists, n = 60; 4 = Placebo manipulative therapy + placebo diclofenac, n = 60 | Twice/day 2-3 times/week 4 weeks | 1. Pain: VAS; time to recovery; 2. Disability: RMDQ; PFS; 3. ADVERSE EVENTS: no harms reported; Data measured at 4 weeks and 3 months | 9/13
Hurley DA (2004)161 | 240 | % male: 52 Mean age: 40.1 yrs | Patients aged 18-65 yrs with acute LBP (duration: 4-12 weeks) with or without pain irradiation to the buttock or legs Acute LBP | 1. MT by chartered Physical therapists , n = 80; 2. IFT-standard stimulation by same therapists, n = 80; 3. MT + IFT by the same therapists, n = 80 | 8 weeks | 1. Pain: VAS; McGill pain questionnaire; SF-36 Bodily pain; 2. Disability: RMDQ; 3. ADVERSE EVENTS: no harms reported; Data measured at 8 weeks, 3 and 6 months | 6/13

Table 1.24 Low Back Pain – Manipulation + Mobilization – Chronic-Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Aure, O (2003)162 Norway | 49 | % male: 53 Mean age: 40.2 yrs | Men and women age 20 to 60 years that had been sick-listed between 8 weeks and 6 months due to LBP with or without leg pain. | 1. Manual Therapy by a specialist, n = 27; 2. Exercise Therapy by 2 physiotherapists, n = 22 | 16 treatments 8 weeks | 1. Pain: VAS (100 mm); 2. Disability: Oswestry LBP Questionnaire; 3. Work: N of sick-listed patients at each assessment session (Analysis’ based on intention to treat); Data measured at 8 weeks, 3 and 6 mo | 8/13
Ferreira ML (2007)163 Australia | 240 | % male: 31 Mean age: 53.6 yrs | Patients with Non-specific CLBP aged 18-80 yrs; Patients with OA, disc protrusion, or herniation without neurological compromise were also included | 1. Spinal manipulation + mobilization by physiotherapists, n = 80; 2. MC + exercise by the same therapists, n = 80; 3. GEN exercise by the same therapists, n = 80 | 12 sessions 8 weeks | 1. Pain: VAS; 2. Disability: RMDQ; PSFS; 3. ADVERSE EVENTS: no harms reported; Data measures at 8 weeks, 3 and 6 mo | 7/13

Table 1.25 Low Back Pain – Manipulation + Mobilization – Mixed- Specific Pain- No trials

Table 1.26 Low Back Pain – Manipulation + Mobilization – Mixed-Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Hurwitz, El (2006)164 US | 681 | % male: 48 Mean age: 51 years | Health maintenance organization membership, sought care in one of the study sites between 1995-1998 with LBP, had no treatment received for the past month, age ≥ 18 yrs | 1. Spinal manipulation/mobilization by chiropractors with ≥ 5 yrs experience, n = 169; 2. Spinal manipulation/mobilization by the same chiropractors, n = 172; 3. MC,-instruction in proper back care, exercises, prescriptions by family medicine practitioners, n = 170; 4. MC + PT- one PM by licensed physiotherapists, n = 170 | 6 weeks | 1. Pain: VAS-most severe; average; 2. Disability: RMDQ; 3. Utility of conventional care: OTC use; prescribed use; mean n of back related visits; 4. ADVERSE EVENTS: no harms reported; Data measured at 2 and 6 weeks, 6 and 18 mo | 6/13
Koes, B (1992)165 Netherlands | 136 | % male: 52 Mean age: 42.8 yrs | Pain or self-reported limited range of motion in the back or neck for at least 6 weeks | 1. Spinal manipulation/mobilization by a manual therapist, n = 36; 2. Physiotherapy by a physiotherapist, n = 31; 3. Continued treatment with General practitioner, n = 39; 4. Physical exam and detuned shortwave diathermy by a physiotherapist, n = 30 | Maximum duration of 3 mo 4 – 2 times/week for 6 weeks | 1. Physical measures: Improvement in spinal mobility-mean change of ROM at T1 measured by inclinometer-spinal forward flexion; 2. ADVERSE EVENTS: no harms reported; Data measured at 6 and 12 weeks | 5/13
Macdonald, R (1989)166 London | 95 | % male: 41 Mean age: NR | Patients between 16 and 70, presenting to their general practitioner with pain partly or wholly between the inferior angles of the scapula and the buttock folds | 1. Spinal manipulation/mobilization by a registered osteopath, n = 49; 2. Control, advice; patients seen in clinic for examination, n = 49 | 2 times/week until cured | 1. Pain: Pain Disability Index; Pain Analog; 2. Disability: Activity Loss (ALA); 3. ADVERSE EVENTS: Excess lumbar lordosis; pins and needles; Data measured at end of treatment | 5/13

Table 1.27 Low Back Pain – Manipulation + Mobilization – Unknown -Specific Pain- No trials

Table 1.28 Low Back Pain – Manipulation + Mobilization – Unknown -Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Meade, TW (1991)167-170 UK | 741 | % male: 51 Mean age: 38.6 yrs | LBP mechanical origin, no contraindicatio n to SM, no treatment within the past month | 1. Spinal manipulation/mobilization by chiropractors, n = 384; 2. HM-Maitland mobilization/manipulation by hospital staff, n = 357 | 1. Maximum 10 sessions 30 weeks; 2. 12 weeks | 1. Disability: ODQ; ODQ pain intensity; 2. Utility of conventional care: % patients using analgesic/NSAIDs drugs; 3. ADVERSE EVENTS: no harms reported; Data measured at 6 mo, 1 year and 2 yrs post-R | 5/13
Sims-Williams H (1979)171 UK | 94 | % male: 58.3 Mean age: 42.7 yrs | Patients with non-specific LBP | 1. Spinal manipulation/mobilization n = 48; 2. Placebo, n = 46 | Assuming 15 sessions 4 weeks | 1. Disability: Spinal movement- Flexion; Extension; 2. ADVERSE EVENTS: no harms reported; Data measured at 4 weeks and 3 mo | 4/13

Table 1.29 Low Back Pain – Flexion Distraction Technique – Acute/Subacute- Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Kominski, G.F (2005)164,172 | 681 | % male: 52 Mean age: 51.1 years | Adults with complaint of LBP (with or without leg symptoms) | 1. Medical care only, by primary care physician, n = NR; 2. Medical care with physical therapy, by physical therapist, n = NR; 3. Chiropractic care only, by chiropractor, n = NR; 4. Chiropractic care with physical modalities, n = NR | NR | 1. Pain: pain scale, lower-extremity pain (0-10 scale); 2. Quality of Life: SF-36 emotional and physical function scores (0-100 scale) | 3/13

Table 1.30 Low Back Pain – Flexion Distraction Technique – Chronic- Specific- No studies

Table 1.31 Low Back Pain – Flexion Distraction Technique – Chronic -Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Cambron JA (2006)173 US | 235 | % male: 63 Mean age: 41.6 yrs | Patients aged > 18 yrs with chronic LBP > 3 months from L1 to S1 joint inclusive, willing to undergo narcotic/NSAI Ds muscle relaxant’s use | 1. Flexion + distraction by a chiropractor with postgraduate certification in the technique, n = 123; 2. Exercise by licensed physiotherapists, n = 112 | 2-4 times/week 4 weeks | 1. Pain: VAS; VAS, Patients with radiculopathy; VAS, Patients without radiculopathy; 2. Disability: RMDQ; 3. Utility of conventional care: annual mean N of visits; healthcare utilization; 4. ADVERSE EVENTS: no harms reported; Data measured at 4 weeks, 3 and 6 mo, 1 yr | 3/13

Table 1.32 Low Back Pain – Flexion Distraction Technique – Mixed - Specific- No studies

Table 1.33 Low Back Pain – Flexion Distraction Technique – Mixed - Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Hawk, C (2005)174 Midwestern US | 111 | % male: NR Mean age: 52 yrs | 18 yrs and over, with sub-acute (onset 4-12 weeks prior to contact) or CLBP (onset more than 12 weeks prior) | 1. Flexion distraction technique by 4 experienced licensed chiropractors in FDT and TP therapy, n = 54; 2. Control-Manipulation, n = 57 | 8 treatments 3 weeks | 1. Pain: PDI; RMQ; VAS (100 mm); 2. ADVERSE EVENTS: no harms reported; Data measured at 3 weeks | 8/13
Hawk C (1999)175 | 13 | % male: 66.6 Mean age: 33. 5 yrs | 18 years of age or older; self-report of LBP within the last 6 mo | 1. Chiropractic Adjustment (active)- Flexion distraction technique by a licensed doctor of chiropractic (DC) certified in FDT, n = 8; 2. Placebo-Sham adjustments by the same doctor, n = 5 | 4 visits 2 weeks | 1. Pain: VAS (10 cm); 2. Quality of Life: Global Well-Being scale (GWBS) (VAS, 10 cm); 3. ADVERSE EVENTS: no harms reported; Data measured at 2 weeks | 4/13

Table 1.34 Low Back Pain – Flexion Distraction Technique – Unknown - Specific- No studies

Table 1.35 Low Back Pain – Flexion Distraction Technique – Unknown -Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Beyerman, KL (2006)176 US | 217 | % male: NR Mean age: NR | English speaking patients with arthritis, OA, degenerative joint/disc disease, facet arthropathy, capable of traveling to the appointments | 1. Flexion distraction technique + moist hot pack, n = 124; 2. Moist heat, n = 93; Treatment provider: NR | 20 sessions 5 weeks | 1. Disability: ODQ pain intensity; ODQ (ADL); 2. ADVERSE EVENTS: no harms reported; Data measured at 5 weeks | 4/13

Table 1.36 Low Back Pain - Massage – Acute/Sub-acute - Specific Pain – No studies

Table 1.37 Low Back Pain - Massage – Acute/Sub-acute - Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Preyde M (2000)177 Canada | 98 | % male: 48.2 Mean age: 46.2 years | 18 - 81 years; existence of sub-acute (between 1 week and 8 months LBP; stable health. | 1. Comprehensive massage therapy by 2 massage therapists with more than 10 yrs experience, n = 25; 2. Soft-tissue manipulation by the same therapists, n = 25; 3. Remedial exercises by the same therapists, n = 22; 4. Sham laser treatment by 1 massage therapists with more than 10 yrs experience and 1 certified personal trainer and certified weight-trainer supervisor, n = 26 | 6 treatments 1 month | 1. Disability: RMDQ; Modified Schober test; 2. Pain: MPQ (PRI and PPI scores); 3. ADVERSE EVENTS: no harms reported; Data measured at 3 mo | 6/13
Pope, M (1994)111 California, US | 240 | % male: 62 Mean age: 32 yrs | Ages 18-55 years; general good health; LBP between 3 weeks and 6 months duration (this episode); free from LBP for minimum 3 weeks for this episode | 1. Manipulation by 5 licensed chiropractors, n = 60; 2. Soft-tissue massage by 2 massage therapists serving as chiropractic interns, n = 30; 3. Transcutaneous muscle stimulation by 1 licensed chiropractor, n = 30; 4. Lumbosacral corset by 1 licensed chiropractor, n = 30 | 9 sessions 3 weeks | 1. Pain: 10 cm VAS; 2. Disability: Rage of motion-Schober’s test – Extension; Flexion; 3. ADVERSE EVENTS: no harms reported; Data measured at 3 weeks | 5/13
Konrad K (1992)178 Hungary | 158 | % male: 44.7 Mean age: 41.5 | NS LBP with or without radiation to the thigh, 1 months <= duration <= 3 mo, a pain free year before the present episode | 1. Balneotherapy, n = 35; 2. Underwater traction bath, n = 44; 3. Underwater massage, n = 26; 4. Control, no treatment, n = 53; Treatment provider: NR | 4 weeks | 1. Pain: VAS; 2. Utility of conventional care: N of analgesics taken in past 24 hrs; 3. ADVERSE EVENTS: no harms reported; Data measured at 6 mo | 6/13
Farasyn A (2006)179 Belgium | 60 | % male: 41.3 Mean age: 41.3 years | 21 - 75 years; N-S sub-acute LBP with or without referred pain to the leg | 1. Placebo by 2 male manual therapists with minimum 2 yrs experience in physical examinations and pressure pain, n = 20; 2. Massage by same manual therapists, n = 20; 3. Control, no treatment by same manual therapists, n = 20 | One 30 min session | 1. Pain: VAS (100 mm); 2. Disability: ODI; 3. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 7/13
Yip, YB (2004)180 China | 61 | % male: 15.0 Mean age: 44.0 – 48.1 years | Patients 18 years old or older with non- specific sub-acute low back pain for most days in the past 4 weeks who had not received acupuncture, manipulation, or physiotherapy in the past week | 1. Acupoint stimulation for relaxation with electrode pads followed by acupressure massage with natural aromatic lavender oil and conventional treatment, n = 32; 2. Conventional treatment alone, n = 29 | 8 sessions of 35-40 min each for 3 weeks | 1. Pain (VAS); 2. Walking time (in sec); 3. Lateral fingertip-to-floor distance (cm) | 5/13

Table 1.38 Low Back Pain - Massage - Chronic- Specific Pain – No Studies

Table 1.39 Low Back Pain - Massage - Chronic - Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Little, P (2008)181-183 UK | 579 | % male: 30.5 Mean age: 45.5 years | Patients with recurrent or CLBP, presenting to primary care with LBP > 3 months (currently scoring ≥ 4 on Roland disability scale, current pain for ≥ 3 weeks (to exclude recurrence of short duration) | 1a Massage only; 1b Massage + Exercise, n = 147; 2a Six Alexander technique lessons; 2b Six Alexander lessons + Exercise, n = 144; 3a 24 Alexander lessons; 3b 24 Alexander lessons + Exercise, n = 144; 4a Usual care; 4b Usual care + Exercise, n = 144 | 1. 6 sessions, 6 weeks; 2. 6 sessions, 4 weeks; 3. 24 lessons in 5 mo; 4. 4b started exercise treatment at 6 weeks | 1. Pain: median days with no pain (IQR); 2. Disability: Roland disability score; 3. Quality of Life: SF-36 physical score; 4. ADVERSE EVENTS: no significant harms reported; Data measured at 3 and 12 mo | 8/13
Zaproudina, N (2009)184 Finland | 122 | % male: 49 Mean age: 41 years | Chronic LBP with or without referred leg pain; minimal VAS of 30 and/or Oswestry Disability Index of at least 16%. | 1. physical and exercise therapy by an experienced registered therapist, n = 63; 2. Traditional bone setting by a Finnish bone-setter, n = 59 | 1. Five sessions; 2. Three - Five sessions lasting 90 minutes per patient at 1 or 2 week intervals | 1. Pain: VAS (0-100) | 5/13
Quinn, F (2008)185 UK | 15 | % male: 32.2 Mean age: 43.5 years | Staff employed at the U of Ulster with non-specific LBP, any physiotherapy, medication or other treatment for LBP has been stabilized for at least 3 mo | 1. Massage-reflexology by 3 experienced reflexologists, n = 7; 2. Sham (foot massage) by the same therapists, n = 8 | 1 treatment/week 6 weeks | 1. Pain: VAS-primary outcome measure; MPQ; 2. Disability: RMDQ; SF-36 health survey; 3. ADVERSE EVENTS: no harms reported; Data measured at 3 mo | 9/13
Poole H (2007)186 UK | 290 | % male: 40.8 Mean age: 46.8 years | 18 - 65 yrs with benign CLBP | 1. Massage-reflexology by 5 experienced reflexologists, n = 77; 2. Relaxation by an experienced certified therapist, n = 82; 3. standard treatment by general practitioner-non-intervention, n = 131 | 6 treatments 6-8 weeks | 1. Pain: SF-36; VAS; 2. Disability: ODQ; physical functioning SF-36; BDI II; 3. ADVERSE EVENTS: no harms reported; Data measured at 6 mo | 5/13
Hsieh LLC (2006)187 Taiwan | 129 | % male: 30 Mean age: 51.4 yrs | Patients aged > 18 yrs with CLBP (> 4 mo) | 1. Acupressure by a senior acupressure therapist, n = 64; 2. PT by a physical therapist, n = 65 | 6 sessions 1 mo | 1. Pain: VAS; Core outcome measures; 2. Disability: RMDQ score; modified Oswestry score; 3. Work: Satisfaction of life with symptoms; 4. ADVERSE EVENTS: no harms reported; Data measured at 1 and 6 mo | 9/13
Geisser, M (2005)188 Michigan | 100 | % male: 34 Mean age: 40.2 yrs | Aged 18-65 yrs; single or primary complaint of CLBP and were judged to have musculoskelet al pain based on evaluation by the physician or physical therapist | 1. Manual therapy, Specific Exercise by a physical therapist with 12 yrs post-grad training in manual medicine, n = 26; 2. Sham therapy, specific exercise by the same therapist, n = 25; 3. Manual therapy, non- specific exercise by the same therapist, n = 24; 4. Sham therapy by the same therapist, N-S exercise, n = 25 | 5 visits 5 weeks | 1. Pain: VAS; MPQ; 2. Disability: Quebec Back Pain Disability Scale (QBPDS); 3. ADVERSE EVENTS: no harms reported; Data measured at 5 weeks | 3/13
Hsieh, L (2004)189 Taiwan | 146 | % male: 47.7 Mean age: 47.6 years | 16 - 84 yrs with chronic LBP | 1. Massage-Acupressure by a senior acupressure therapist, n = 69; 2. Physical therapy by the same therapist, n = 77 | 6 sessions 4 weeks | 1. Pain: Chinese version of SF-PQ; 2. ADVERSE EVENTS: no harms reported; Data measured at 6 mo | 9/13
Cherkin, DC (2001)27 US | 262 | % male: 41% Mean age: 44.9 yrs | Ages 20 to 70 years who visited a primary care physician for low back pain who had persistent LBP for 6 weeks | 1. acupuncture, n = 94; 2. massage-manipulation of soft-tissue, n = 78; 3. self care education, n = 90 | Up to 10 visits 10 weeks | 1. Pain: symptom bothersomeness during past week; 2. Disability: Roland Disability Scale Score; National Health Interview survey; 3. Quality of Life: SF-12 mental health summary scales; 4. ADVERSE EVENTS: no harms reported; Data measured at 10 weeks and 1 yr | 6/13
Hernandez-Reif M (2001)190 US | 24 | % male: 45.8 Mean age: 40.25 years | Adults with LBP with a duration of at least 6 mo | 1. Massage therapy by trained massage therapists, n = 12; 2. Relaxation-no treatment, n = 12 | 2 sessions/week 5 weeks | 1. Pain: SF-MPQ; VAS; 2. Disability: Range of motion (trunk flexion; pain flexion); 3. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 2/13
Field T (2007)191 US | 30 | % male: 53 Mean age: 41 years | Adults with LBP of a duration of at least 6 mo; cleared by their primary physician to participate in the study | 1. Massage therapy by trained massage therapists, n = 15; 2. Relaxation therapy, n = 15 | 2 session/week 5 weeks | 1. Pain: VAS (10 cm); 2. Disability: Range of motion (trunk flexion; pain flexion); 3. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 2/13
Mackawan S (2007)151 Thailand | 67 | % male: 39 Mean age: 38.8 yrs | 20 - 60 years; persistent chronic LBP (more than 12 weeks); no evidence of underlying diseases or anatomical abnormalities | 1. Traditional Thai Massage (TTM) by an experience physiotherapist, n = 35; 2. Joint Mobilization by the same therapist, n = 32 | One 10 min session | 1. Pain: VAS (10 cm); Substance P levels in saliva (severity of chronic pain); 2. ADVERSE EVENTS: no harms reported; Data measured at end of single session | 5/13
Hollinghurst, S (2008)183 | 579 | % male: 30.5 Mean age: 45.5 years | Chronic or recurrent LBP recruited from primary care | 1. Normal care (no exercise), n = 72; 2. Therapeutic massage (no exercise), by massage therapists, n = 75; 3. Six Alexander technique lessons (no exercise, by teachers, n = 73; 4. Twenty-four Alexander technique lessons (no exercise), n = 73; 5. Normal care + exercise, n = 72; 6. Therapeutic massage + exercise, n = 72; 7. Six Alexander technique lessons + exercise, n = 71; 8. Twenty-four Alexander technique lessons + exercise, n = 71 | 6- 24 sessions | 1. Cost: QALYs; 2. Disability: Roland-Morris disability score; Data measured at 3 and 12 months
Franke, A (2000)192 | 190 | % male: 61.0 Mean age: 43.5 – 45.6 years | Patients with low back pain aged 20 – 55 years, German speaking, chronic back pain > 1 year | 1. acupuncture massage (APM) according to Penzel + individual gymnastic exercise (EG), n = 46; 2. Classical Swedish massage TM + individual gymnastic exercise (EG), n = 49; 3. APM + gymnastic exercises in groups (KGG) by therapists trained according to Penzel, n = 46; 4. KGG + TM, n = 49 | EG: 12-16 sessions each 30 min KKG: in gym – 8-10 sessions each 30 min, in pool 4-6 sessions APM: 4 sessions each 30 min TM: 8 sessions each 15 min | 1. VAS (at baseline and after treatment); 2. Flexion & extension (at baseline and after treatment) | 8/13

Table 1.40 Low Back Pain - Massage - Mixed - Specific Pain – 193

Table 1.41 Low Back Pain - Massage - Mixed - Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Hoehler F (1981)137 California | 95 | % male: 59 Mean age: 31.1 yrs | Presence of palpatory cues indicating that manipulation might be successful | 1. Rotational Manipulation of lumbosacral spine by a physician, n = 56; 2. Soft-tissue massage by a physician, n = 39 | N of treatments varied | 1. Pain: Improvement in amount of pain; 2. ADVERSE EVENTS: no harms reported; Data measured at end of treatment | 3/13
Chatchawan U (2005)194 | 180 | % male: 36 Mean Age: 36.4 years | 21-50 years; persistent BP, either subacute (lasting 4-12 weeks) or chronic (lasting for over 12 weeks) Mixed | 1. Traditional Thai Massage (TTM) by 1 of 3 massage therapists who had 4, 8, and 20 yrs of experience, n = 90; 2. Swedish massage (SM) by the same massage therapists, n = 90 | 6 sessions 3-4 weeks | 1. Pain: VAS (10 cm); 2. Disability: ODQ; 3. ADVERSE EVENTS: no harms reported; Data measured at 3 mo | 6/13
Zhang, J (2004)193 China | 165 | % male: 31.5 Mean age: 41.4 years | 2-60 yrs Diagnosed as Shanghai Chinese Medical Diagnostic and therapeutic Effective Standard Mixed | 1. Traction by a doctor and a hospital staff member, n = 55; 2. Massage by the same treatment provider, n = 55; 3. Massage + Exercise by the same treatment provider, n = 55 | 1 or 3 treatment/week 20 treatments total | 1. Pain: Shanghai Chinese Medical Diagnostic and treatment Standard Procedure; 2. Disability: Function of lumbar spine; 3. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 6/13

Table 1.42 Low Back Pain - Massage - Unknown - Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Li ZY (2006)195 China | 60 | % male: 53.6 Mean age: 45.4 yrs | Typical symptoms; Clinical positive signs; Diagnosed by CT or MRI; age: 20-55 yrs | 1. Massage-Living acupoint treatments, n = 30; 2. Spinal Manipulation- Oblique-pulling, n = 30; Treatment provider: NR | NR | 1. Pain: Score evaluation of pain treatment; VAS; 2. ADVERSE EVENTS: no harms reported; Data measured at end of treatment | 10/13

## Neck Pain

Table 2.1 Neck Pain - Acupuncture - Acute - Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Aigner, N (1999)196 Austria | 74 | % male: NR Mean age: NR | 18-65 years with whiplash for no longer than 4 days | 1. Cervical collar, Chlormezanon, Paracetamol + Acupuncture, n = 28; 2. Cervical collar, Chlormezanon, Paracetamol + Laser Acupuncture, n = 23; 3. Chlormezanon, Paracetamol and cervical collar, n = 33; Treatment provider: NR | NR | 1. Pain: improvement in ROM; 2. Work: sick leave; 3. ADVERSE EVENTS: no harms reported | 6/13

Table 2.2 Neck Pain - Acupuncture - Acute - Non –Specific Pain - No Studies

Table 2.3 Neck Pain - Acupuncture - Chronic - Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Venancio RA (2008)197,198 Brazil | 45 | % male: 11.1 Mean age: NR | Patients 18-65 years with chronic (≥6 mo) myofascial pain and headache | 1. Acupuncture (dry needling), n = 15; 2. Lidocaine injection, n = 15; 3. Lidocaine + Decadron, n = 15; Treatment provider: NR | NR 3 weeks | 1. Pain: pain intensity, frequency, duration (SSI scores); VAS; 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention and 6 mo | 2/13
Ga, H (2007)199 Korea | 39 | % male: 7.5 Mean age: 77.6 years | Patients aged > 60 yrs complaining of chronic shoulder/neck pain or headache for more than 6 mo | 1. Acupuncture by a family physician who completed TP injection courses, n = 18; 2. Lidocaine injection, n = 21 | 3 treatments/week | 1. Pain: Pain intensity: VAS; FACES; PTS; 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention and 3 mo | 5/13
Ga, H (2007)200 Korea | 40 | % male: 7.5 Mean age: 77.8 years | Patients aged > 20 years complaining of chronic shoulder/neck pain or headache for more than 6 mo | 1. Acupuncture by a family physician who completed TP injection courses, n = 18; 2. Acupuncture (IMS), n = 22 | Treatment performed 3 times a week | 1. Pain: pain intensity scores: VAS; FACES; PTS; 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention and 3 mo | 6/13
Lv, YX (2006)201 China | 70 | % male: 38.7 Mean age: 41.4 years | Cervicogenic headache | 1. Probing needling, n = 36; 2. Routine Acupuncture, n = 34; Treatment provider: NR | 12 treatments 12 days | 1. Pain: VAS; 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 3/13
Irnich D [crossover] (2002)202,203 Germany | 102 | % male: 26.4 Mean age: 51.9 years | Patients with chronic NP (> 2 mo) and myofascial or irritation syndrome | 1. non-local-Acupuncture by an acupuncturist with 2 yrs training, n = 34; 2. Local-Acupuncture (Dry Needling) by the same therapist, n = 34; 3. Laser-Acupuncture Sham by the same therapist, n = 34 | 30 min/session immediate post treatment – 1 session | 1 Pain: VAS (0-100) motion-related; 2 ROM; 2 ADVERSE EVENTS: one subject reported mild hypotension and sweating; Data measured immediately post intervention (only crossover data reported) | 8/13
Zhu XM [crossover] (2002)204 Australia | 29 | % male: 52 Mean age: 49.4 years | Patients with chronic NP aged 31-71 years had neck complaints ≥ 6 mo | 1. Acupuncture, n = 14; 2. Sham-Acupuncture, n = 15; Treatment provider: NR | 9 sessions 3 weeks | 1. Pain: Pain intensity-adapted MPQ; VAS; Daily pain duration; 2. Disability: NDI; 3. Healthcare Utilization: Daily use of pain pills; 4. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 7/13
Irnich D (2001)205-207 Germany | 177 | % male: 34 Mean age: 52.4 years | Patients with chronic NP (>1 mo) and painful restriction of cervical spine mobility, not received treatment two weeks before the study | 1. Acupuncture by an experienced and licensed acupuncturists, n = 56; 2. Massage by experienced physiotherapists, n = 60; 3. Sham Laser acupuncture, n = 61 | 5 sessions 3 weeks | 1. Pain: VAS (0-100); PPT; 2. Quality of Life: SF-36: Role physical, Pain Index; 3. ROM; 4. ADVERSE EVENTS: mild reactions (slight pain, sweating, low blood pressure); Data measured at 1 and 3 weeks, and 3 months | 4/13
White, PF (2000)208 U.S. | 204 | % male: NR Mean age: 52 years | Patients with history of NP and cervical disk disease with a stable level of pain for a period of at least 3 months before enrolment | 1. Acupuncture with electrical stimulation at local points, n = 23; 2. Acupuncture with ES at remote points (Low Back region), n = 68; 3. Acupuncture needles only at neck, n = 23; Treatment provider: NR | 9 treatments 3 weeks | 1. Pain: VAS (10 cm) crossover design; 2. Quality of Life: SF-36 crossover design; 3. Healthcare utilization: Daily analgesic decrease; 4. ADVERSE EVENTS: needle site side effects only; Data measured immediately post intervention | 5/13
Lundeburg (1991)209 | 58 | % male: NR Mean age: NR | 44-76 years; osteoarthritis of the cervical and/or thoracic spine (C1-T1), with no previous experience of acupuncture; pain for 6 months or more | 1. Sham-superficial needling by an acupuncturist, n = 14; 2. Manual acupuncture by the same therapist, n = 14; 3. 2 Hz Electrical stimulation by the same therapist, n = 15; 4. 80 Hz Electrical stimulation by the same therapist, n = 15 | One 40 minute session | 1. Pain: pain intensity (sensory) VAS (10 cm); pain unpleasantness (affective) VAS (10 cm); 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 1/13
Cecchereli F (2006)210 Italy | 62 | % male: 26 Mean age: 42.7 years | Myofascial cervical pain | 1. Somatic Acupuncture, n = 31; 2. Acupuncture + Auriculotherapy, n = 31; Treatment provider: NR | 8 sessions 8 weeks | 1. Pain: MPQ; VAS; 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention, 3 and 6 mo | 6/13
Thomas, M (1991)211 Sweden | 44 | % male: NR Mean age: NR | 42-77 years with osteoarthritis of the cervical spine | 1. Acupuncture by an acupuncturist, n = NR; 2. Sham Acupuncture by an acupuncturist, n = NR; 3. Diazepam, n = NR; 4. Sham Diazepam, n = NR | 3-5 days between different trials NR | 1. Pain: (VAS 10 cm sensory) pain intensity; VAS (10 cm) affective; 2. ADVERSE EVENTS: no harms reported; Data measured immediately post treatment | 5/13
Zhao, Z (2004)212 China | 106 | % male: 49.1 Mean age: 46.5 years | Diagnostic using Chinese Standard; X-ray show unstable of neck spinal and discs | 1. Moxibustion + Acupuncture, n = 53; 2. Acupuncture, n = 53; Treatment provider: NR | 10 treatments 20 days (2 courses) | 1. Quality of Life: well-being; 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 3/13
Yang, T (2009)213 China | 66 | % male: 51.5 Mean age: 45.1 years | Spinal cord type and radicular type cervical intervertebral disc | 1. Acupoint sticking therapy, n = 33; 2. Acupuncture, n = 33; Treatment provider: NR | 34 days | 1. Quality of Life: number of effect; 2. ADVERSE EVENTS: n = 2 discontinued treatment due to allergy; Data measured immediately post intervention and 3 mo

Table 2.4 Neck Pain - Acupuncture - Chronic - Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Abernathy, AP (2008)214 | 123 | % male: NR, majority female Mean age: 46.5 years | Patients ≥ 18 years with uncomplicated NP for at least 3 months with motion-included pain of at least 30 on 100 mm VAS | 1. Acupuncture by an acupuncturist, n = NR; 2. TENS, n = NR | 5 sessions 3 weeks | 1. Pain: VAS (0-100 mm) motion; 2. Quality of Life: SF-36 improvement; 3. Medication used (no data provided); 4. ADVERSE EVENTS: mild but not described; Data measured at 1 week post treatment and 6 months post randomization | 0/13
Itoh, K (2007)215 Japan | 40 (cross over design) | % male: 27.5 Mean age: 62.3 years | Patients age at least 45 years, no radiation of neck pain, and no major trauma or systemic disease | 1. Trigger point acupuncture, n = 10; 2. Acupoint acupuncture (standard), n = 10; 3. Non trigger point acupuncture, n = 10; 4. Sham acupuncture, n = 10; All treatments by acupuncturist with 2 – 7 years experience and 4 years training | A pre-cross over period followed by 18 acu treatments 3 weeks | 1. Pain (VAS); 2. Disability (Neck Disability Index); 3. ADVERSE EVENTS: reported | 6/13
Salter GC (2006)216 US | 24 | % male: 25.5 Mean age: 48.2 years | Patients with chronic neck pain aged 18 yrs or older who had consulted the neck pain practice in the previous 12 mo | 1. Acupuncture + standard treatment by acupuncturists and general practitioner, n = 10; 2. general practitioner, n = 14 | 3 months | 1. Pain and disability: NPQ; 2. Drug utilization; 3. ADVERSE EVENTS: aggravation of symptoms, dizziness, tiredness; Data measured immediately post intervention | 6/13
Seidel (2002)217,218 Germany | 51 | % male: 9.8 Mean age: 49.5 years | Patients with cervical pain for at least 6 months aged 20-72 years; no AP treatment for past 6 mo; consent | 1. Low-level laser therapy (LLLT) on AP by a “therapist”, n = 13; 2. LLLT 7 mW, n = 12; 3. LLLT 30 mW, n = 13; 4. Conventional Acupuncture, n = 13 | 8 treatments 4 weeks | 1. Pain: pain intensity VAS (0-10); pain sensation PPT;; 2. Disability: Cervical movement function; 3. Physical Measures: cervical mobility; mental health questionnaire; 4. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention and 1 mo | 10/13
Petrie, J (1986)219 United Kingdom | 25 | % male: 36.5 Mean age: 50.5 years | Chronic neck pain (at least 6 months) | 1. Acupuncture + analgesic, n = 13; 2. Sham transcutaneous nerve stimulation (TNS) + analgesic, n = 12; Treatment provider: NR (author administered the treatment) | 8 sessions 4 weeks | 1. Pain: MPQ-PRI based on word rank; Daily pain score-VAS (0-10)-; 2. ADVERSE EVENTS: no harms reported; Data measured at 4 weeks | 5/13
Petrie, JP (1983)220 New Zealand | 13 | % male: 32.2 Mean age: 65 years | Chronic cervical pain (> 2 yrs) defined as NP radiating to the occipital and/or shoulders with some limitations in movement | 1. Acupuncture, n = 7; 2. TENS-placebo; Treatment provider: NR | 8 sessions 4 weeks | 1. Pain: pain relief: 5-pt simple scale (no relevant outcome reported); 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 6/13
Gallacchi G (1983)221,222 Switzerland | 113 | % male: NR Mean age: NR | Tendomyotical cervical and lumbar syndrome were under medical and/or physical treatment for number of months before volunteered for acupuncture study (data reported for cervical pain) | 1. AP conventional needle AP at classical acupuncture points by a physician, n = 15; 2. PN conventional needle AP at classical acupuncture points with placebo needles, n = 14; 3. PP needle acupuncture at placebo points, n = 14; 4. Laser AP at classical acupuncture points- laser light, n = 15; 5. Laser AP at classical a acupuncture points-no emission of rays, n = 14; 6. Laser AP at classical a acupuncture points-mixed light, n = 14; 7. Laser AP at classical a acupuncture points-red light, n = 13; 8. Laser AP at classical a acupuncture points-infrared light, n = 14 | 8 treatments 4 weeks | 1. Pain: VAS (Scale NR); 2. VAS muscle tension; 3. ADVERSE EVENTS: no harms reported | 5/13
Coan RM (1982)223 US | 30 | % male: 26.7 Mean age: 49.3 years | chronic Neck pain and/or radicular arm and hand pain ≥6 mo | 1. Acupuncture + electroacupuncture or Moxibustion was used on some subjects, n = 15; 2. wait list control, n = 15; Treatment provider: NR | 3-4 times/week 8 weeks | 1. Pain: VAS (0-10); mean number of hrs with pain/day; 2. mean number of pain pills used; 3. ADVERSE EVENTS: no harms reported; Data measured at 3 mo | 4/13
Giles, LGF (1999)129 Australia | 40 | % male: 35.7 Mean age: 41.3 years | Patients suffering from NP for at least 13 weeks, at least 18 years of age | 1. Acupuncture, n = 10; 2. Manipulation, n = 20; 3. Medication [tenoxicam (NSAID) with ranitidine], n = 10; Treatment provider: NR | 6 treatments 3-4 weeks | 1. Pain: VAS (0-10); 2. Disability: NDI (0-50); 3. ADVERSE EVENTS: no side effects occurred for acupuncture or manipulation; Data measured immediately post intervention | 1/13
David, J (1998)224 UK | 70 | % male: 28.6 Mean age: 46 years | Patients aged 18-75 years with chronic neck pain (> 6 weeks) and WAD | 1. Acupuncture by general practitioners registered with the BMAS, n = 35; 2. PT (Maitland mobilization) by a senior physiotherapist, n = 35 | 6 sessions 6 weeks | 1. Pain: VAS (0-100); NPQ; 2. Quality of Life: GHQ; 3. ADVERSE EVENTS: no harms reported; No numerical data given, data measured at 6 weeks and 6 mo | 4/13
Vas, J (2006)225 Spain | 123 | % male: 18 Mean age: 46.7 yrs | 17 yrs and over with uncomplicated NP over 3 months duration; symptomatic at examination; motion-related NP intensity 30 and over on 100mm VAS, no treatment during past week | 1. Acupuncture by a doctor with over 15 years of clinical experience, n = 61; 2. TENS placebo, unclear who administered the treatment, n = 62 | 5 sessions 3 weeks | 1. Pain: VAS(0-100 mm); NPQ (Spanish); 2. Disability: ACM (Active Cervical Mobility; PCM (Passive Cervical Mobility); 3. Quality of Life: SF-36 physical score; 4. Utility of conventional care: N of doctor visits in past 3 mo; 5. ADVERSE EVENTS: swelling of the hand, bruising, pain, ulcer of the ear; cephalea, aggravation of symptoms; Data measured at 3 weeks and 3 mo | 7/13
White P (2004)226,227 | 135 123 of 235 were analyzed | % male: 35.6 Mean age: 53.4 years | Patients aged 18-80 years with chronic mechanical neck pain (> 2 months) and a pain score > 30 mm on VAS (0-100 mm) for 5 of 7 pre-treatment days | 1. Acupuncture by an acupuncturist with 7 years of experience, n = 70; 2. TENS-Placebo by the same therapist, n = 65 | 8 sessions 4 weeks | 1. Pain: VAS (0-100); 2. Disability: NDI; 3. Quality of Life: PCS/SF-36; 4. Healthcare utilization: daily consumption of acetaminophen tablets; 5. ADVERSE EVENTS: increase in symptoms, faintness, swelling of the hand, bruising, mild headache, euphoria and enhanced vision, dizziness; Data measured immediately post treatment, 8 weeks and 6 mo, 12 mo | 9/13
Sator-Katzenschlager SM (2003)228 Austria | 21 | % male: 28.5 Mean age: 52 years | Chronic cervical pain (≥ 6 mo), normal neurologic function, of cervical nerves with no pain radiation, neural or spinal structure pathology, VAS≥5 | 1. M-Au-Acupuncture, n = 11; 2. EI-Au-Acupuncture, n = 10; Treatment provider: NR | Once/week 6 weeks | 1. Pain: VAS (no numerical data); 2. Quality of Life: well-being(no numerical data); 3. Utility of conventional care: utilization of rescue medication; 4. ADVERSE EVENTS: no harms reported; Data measured at 3 mo | 4/13
Nabeta, T (2002)229 Japan | 34 | % male: 29.4 Mean age: 32.5 years | Patients with chronic pain/stiffness in neck and shoulder without arm symptoms | 1. Acupuncture by well- trained acu instructors, n = 17; 2. Sham-Acupuncture by the same instructors, n = 17 | 3 treatments at weekly intervals 3 weeks | 1. Pain: VAS (0-10); PPT; 2. ADVERSE EVENTS: no harms reported; Data measured at 3 weeks and 3 mo | 5/13

Table 2.5 Neck Pain - Acupuncture - Mixed - Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Bin, X (2007)230 | 57 | % male: 26.3 Mean age: NR | 35-68 years; diagnostic riteria of western edicine | 1. Electro-acupuncture, n = 29; 2. Control-Simple acupuncture, n = 28; Treatment provider: NR | 20 treatments | 1. Therapeutic effects; 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 5/13
Shang, Xiu-kui (2002)231 China | 80 | % male: NR Mean age: NR | Diagnostic as nerve-root cervical spondylopathy using Chinese Medical Diagnostic Standard | 1. Acupuncture, acupoint Sitianxue, n = 50; 2. Acupuncture, acupoint Jiajixue, n = 30; Treatment provider: NR | 1 treatment/2 days 9 treatments/course, 3 courses | 1. Pain: Scoring based on Chinese Medical Diagnostic and therapeutic Effective Standard for Neck Disease; 2. Quality of Life: Scoring based on Chinese Medical Diagnostic and therapeutic Effective Standard for Neck Disease; 3. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention
Li, Xiang-hui (2004)232 China | 780 | % male: 46.4 Mean age: 49 years | Patients diagnosed as cervical spondylosis using Chinese Medical Diagnostic and Effectiveness Standard | 1. Acupuncture Centro-square needling Danzhui, n = 260; 2. Acupuncture needling cervical Jiaji point, n = 260; 3. Traction-Massage, n = 260; Treatment provider: NR | 20 treatments 20 days | 1. Quality of Life: well-being based on Chinese Medical Diagnostic and therapeutic Effective Standard; 2. ADVERSE EVENTS: no harm reported; Data measured immediately post intervention and 1 yr | 4/13
Zhang, Honglai (2003)84 China | 120 | % male: 54.2 Mean age: NR | Diagnosed as Cervical Spondylosis using ref[1] 1993-Chinese; compliant to treatment, responded to surveys | 1. Electro-acupuncture, n = 60; 2. Traction, n = 60; Treatment provider: NR | 45 treatments 45 days, 2 days rest between courses-3 courses | 1. Pain: McGill PRI; VAS; PRI; 2. Quality of Life: Cure, improved, effective, no effect; 3. ADVERSE EVENTS: no harms reported; Data measured after each of the 3 courses | 6/13
Zhuang, Li-Xing (2004)233 China | 34 | % male: 29.4 Mean age: 53.5 years | Patients diagnosed as vertebral artery type of cervical spondylosis by Western Medicine, 36-72 years, duration 1 mo-5 yr, also diagnosed by Chinese medicine | 1. Pressed Acupuncture at the Baihui acupoint + Local Electro-Acupuncture by trained professionals, n = 17; 2. Local Electro-Acupuncture by trained professionals, n = 17 | 21 treatments 21 days | 1. Quality of Life: well being: scoring based on Chinese Medical Diagnostic and therapeutic Effective Standard 1995; 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 4/13
Lin, M (2004)234 China | 100 | % male: 65 Mean age: 46 years | Cervical spondylopathy of nerve root type, aged 25-76 years | 1. Needle scalpel combined with Massage therapy, n = 50; 2. Simple Massage therapy, n = 50; Treatment provider: NR | 21 treatments 3 months | 1. Quality of Life: Cure; 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 3/13
Chu J (1997)235 US | 164 | % male: 34.8 Mean age: NR | Neck and arm pain, MPS due to cervical nerve root irritation | 1. Acupuncture (dry needling)-tender points, n = 122; 2. Acupuncture (dry needling)-random points, n = 42; Treatment provider: NR | NR | 1. Pain: ≤ 50% pain relief; 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 1/13
Zhu, HZ (2006)236 China | 221 | % male: 50.8 Mean age: 46.3 years | 18-75 years with cervical spondylosis | 1. Needle-knife therapy, n = 115; 2. Acupuncture, n = 106; Treatment provider: NR | 9 treatments 1 treatment/3-5 days | 1. Pain: Overall efficiency; 2. ADVERSE EVENTS: no harms reported; Data measured at 6 mo | 4/13
Cun-sheng jia, Jing Shi, Xio-shun Ma, Xiao-feng Li, Ying Wang, Jing-lan Wang (2007)237 China | 98 | % male: 51 Mean age: NR | Diagnosed as cervical spondylosis according to “The diagnostic criteria for cervical spondylosis”; NP; consent | 1. Otopoint-penetrative needling by a neuropathy doctor, n = 49; 2. Otopoint-straight needling by the same doctor, n = 49 | 30 minutes total | 1. Pain: SF-MPQ; 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 5/13
Yuan-fang Huang, Tai-fen Wang, Yan liu, Shi-xing Zhang (2008)238 China | 107 | % male: 65.5 Mean age: 42.1 years | Numbness, NP and radiating pain towards upper limb | 1. Acupuncture at Jiquan (HT1) with lifting thrusting manipulation by a neuropathy doctor, n = 37; 2. Acupuncture at Jiquan (HT1) with twirling manipulation by the same doctor, n = 36; 3. Routine needling by the same doctor, n = 34 | 10 sessions 20 days | 1. Physical Measures: Traditional Chinese medicine diagnostic efficacy standards: cure, effective, ineffective; 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 4/13
Xi lin Wang (2008)239 China | 102 | % male: 51 Mean age: 44.2 years | NP, neck pressure pain and/or radiating pain | 1. Shu-needling + Electro-Acupuncture by a neuropathy doctor, n = 51; 2. Routine needling + Electro-Acupuncture by a neuropathy doctor, n = 51 | 30 sessions 30 days | 1. Disability: Efficacy of TCM diagnostic criteria; 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 4/13
Zhang, W (2005)240 China | 96 | % male: 60.9 Mean age: NR | Patients with cervical sponodylosis | 1. Acupuncture + Massage/Manipulation, n = 64; 2. Control-Massage, n = 32; Treatment provider: NR | 9 sessions 3 weeks | 1. Quality of Life: Cure rate; total effective rate; 2. ADVERSE EVENTS: no harms reported | 0/13

Table 2.6 Neck Pain - Acupuncture - Mixed Duration of Disorder - Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Fu ZH (2007)241 China | 47 | % male: 32.5 Mean age: NR | 18-80 years, TrP in neck/upper back for 10 days-1 yr Acute – sub-acute | 1. FSM-Along (insertion along the local muscle fibres pointed to the MTrP), n = 22; 2. FSM-Across (insertion across the local muscle fibres pointed to the MTrP), n = 25; Treatment provider: NR | One treatment (24 hrs) | 1. Pain: MRP scores; PUP scores; 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 4/13

Table 2.7 Neck Pain - Acupuncture – Unknown duration of disorder - Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Liang, Z (2009)242 China | 108 | % male: 18.9 Mean age: 33.9 years | 18-60 years; no acupuncture treatment for NP within 6 mo; signed consent form | 1. Acupuncture, n = 54; 2. Control-Acupuncture, n = 54; Treatment provider: NR | 3 weeks | 1. Pain: Northwick Park NP Questionnaire; 2. Disability: not measured; 3. number of all effect/number of total patients; 4. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention
Zheng, Ling (2005)243 China | 60 | % male: NR Mean age: 52 years | No surgery; Diagnostic as cervical spondylopathy by ref[1]-A Chinese paper; coronary heart disease, rheumatism | 1. Point-through-point Acupuncture, n = 30; 2. General Acupuncture, n = 30; Treatment provider: NR | 30 treatments 30 days(2 courses), 3 days between courses | 1. Pain: Number of patients who have pain-Chinese paper, Internal Medical Disease Diagnosis standard; 2. Quality of Life: well-being, scoring based on Ref[1]; 3. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 5/13
Xi-lin Wang, Hai-yan Huang (2007)244 China | 120 | % male: 54.2 Mean age: 47.8 years | Diagnosed as Cervical Spondylosis according to “Chinese medicine clinical research guiding principles” | 1. Needle retention at GV 20 for 8 hrs and Electro-Acupuncture at local points by a neuropathy doctor, n = 60; 2. Needle retention at GV 20 for 30 min and Electro-Acupuncture at local points by the same doctor, n = 60 | 30 sessions total 30 days | 1. Pain: NR; 2. Quality of Life: Cured; 3. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 3/13
Fu, W (2005)245 China | 158 | % male: 55.1 Mean age: 34.5 years | Western Medical and Chinese Medical Diagnostic Standards to Diagnostic | 1. Needle picking Acupuncture, n = 56; 2. Local anaesthesia, n = 47; 3. Normal Acupuncture, n = 55; Treatment provider: NR | 8 treatments 4 weeks | 1. Pain: PRI; 2. Quality of Life: Well-being, scoring based on Chinese paper ref[1]; 3. ADVERSE EVENTS: too much pain to continue treatment, scars left after treatment; Data measured immediately post intervention | 3/13
Edwards J (2003)246 UK | 40 | % male: 30.7 Mean age: 56.3 years | Patients aged ≥ 18 years with active MTrPs, consent and compliance | 1 SDN + Stretching exercise, n = 14; 2 Stretching exercise, n = 13; 2 No treatment, n =13; Treatment provider: NR | 3 weeks | 1. Pain: SFMPQ; PPT; 2. ADVERSE EVENTS: no harms reported; Data measured at 3 weeks and 3 mo | 6/13
Duann, J (2007)247 Taiwan | 72 | % male: NR Mean age: NR | Cervical myofascial pain syndrome | 1. Mini scalpel-needle (MSN) Treatment, n = 36; 2. Lidocaine Trigger Point Treatment, n = 36; Treatment provider: NR | One treatment (30 s, 30 min observation) | 1. Pain: pain intensity VAS; 2. Disability: NP and Disability CAS (NPDVAS); 3. Tripper Point Evaluation; 4. ADVERSE EVENTS: no harms reported; Data measured at 2 weeks, 2 and 3 mo | 2/13

Table 2.8 Neck Pain - Acupuncture - Unknown - Non-Specific Pain – No studies

Table 2.9 Neck Pain - Manipulation & Mobilization Therapies - Acute - Specific Pain – No studies

Table 2.10 Neck Pain - Manipulation & Mobilization - Acute - Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Population (Gender, Age) Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Buchmann, J (2005)248 Germany | 27 | % male: 57.3 Mean age: 46.3 years | 18 -80 years, manually diagnosed dysfunction of one or both of the segments occipital/cervical 1 and cervical 1/cervical 2 | 1. Spinal Manipulation by a neurologist experienced in manual and osteopathic medicine, n = 10; 2. Postisometric Relaxation (mobilization) by the same neurologist, n = 8; 3. Placebo by the same neurologist, n = 8 | NR | 1. Disability: Number of found dysfunctions in motion segments; 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 7/13
Pikula, J (1999)249 Brantford, ON | 36 | % male: 22 Mean age: 42.1 yrs | Acute unilateral NP; no prior similar history; no history of trauma; no neurological deficit; no previous chiropractic treatment of cervical spine | 1. Spinal Manipulative Therapy (SMT) applied to same side as pain (ipsilateral) by a chiropractor, n = 12; 2. SMT applied to opposite side of pain (contralateral) by the same chiropractor, n = 12; 3. Placebo Ultrasound Therapy, n = 12 | One single treatment | 1. Pain: VAS (100 mm)(0-100) for pain intensity; 2. Disability: CROM for cervical range of motion; 3. ADVERSE EVENTS: no harms reported; Data measured at end of treatment session | 4/13
Yurkiw, D (1996)250 Canada | 14 | Male (%): 27.3 Mean age: 37.4 years | Unilateral neck pain | 1. manipulation by a chiropractor, n = 7; 2. mechanically assisted manipulation by the same chiropractor, n = 7 | Single treatment session | 1. Pain: VAS (0 – 10) lower values better; 2. Physical Measures: range of motion; 3. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 7/13
Gonzalez-Iglesias, J (2009)251 | 45 | Male (%): 53.4 Mean age: 34.5 years | Mechanical neck pain | 1. thoracic spine thrust manipulation + electro thermal therapy, n = 23; 2. electrothermal therapy, n = 22; Treatment provider: NR | Once per week (5 electro/ther mal therapy) 3 weeks | 1. Pain: VAS 100 mm- lower values better; 2. Disability: Northwick Pain Questionnaire - Spanish version (max score = 36); Measured at 2 and 4 week | 9/13

Table 2.11 Neck Pain - Manipulation & Mobilization - Chronic - Specific Pain – No studies

Table 2.12 Neck Pain - Manipulation & Mobilization - Chronic - Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Giles, LG (2003)17,252 Australia | 115 | % male: 54.9 Mean age: 26.1 years | At least 17 years with uncomplicated mechanical spinal pain for minimum of 13 weeks | 1. Acupuncture (LB, Neck, Thorax), n = 36; 2. Spinal Manipulation by a chiropractor, n = 36; 3. Medication that has not been tried by patients randomized to this group by a sports physician, n = 43 | 2 treatments/week Up to 9 weeks | 1. Pain: pain intensity and frequency neck VAS-lower values better; 2. Disability: NDI; Oswestry-lower values better; 3. Quality of Life: SF-36-higher values better; 4. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 5/13
Giles, LGF (1999)129 Australia | 40 | % male: 35.7 Mean age: 41.3 years | Patients suffering from NP for at least 13 weeks, at least 18 years of age | 1. Acupuncture, n = 10; 2. Manipulation, n = 20; 3. Medication, n = 10; Treatment provider: NR | 6 treatments 3-4 weeks | 1. Pain: VAS; 2. Disability: ODI; 3. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 1/13
Sloop, P (1982)253 NR | 39 | Male (%): 33 Mean age: 49 years | 19-68 years with non-specific or cervical spondylosis NP | 1. manipulation by a rheumatologist experienced in manipulation, n = 21; 2. no treatment (delayed manipulation) by a physician, n = 18 | Single treatment session | 1. Pain: VAS (0 – 8); Measured immediately post intervention and at 3, 12 week | 5/13
Cleland, J (2005)254 New Hampshire, US | 36 | % male: 24.9 Mean age: 35.5 yrs | 18 – 60 yrs with primary complaint of mechanical NP, referred by primary care physician to outpatient orthopaedic physical therapy clinic. | 1. Thoracic Spine Manipulation by a licensed physical therapist, n = 19; 2. Placebo Manipulation by the same therapist, n = 17 | One treatment | 1. Pain: VAS to assess resting pain (0-100 mm); 2. Disability: NDI to assess perceived disability due to NP; 3. ADVERSE EVENTS: no harms reported; Data measured at end of single treatment | 7/13
Bischoff, A (2003)255 NR | 49 | Male (%): NR Mean age: NR | Non-specific neck pain | 1. osteopathic intervention + sham ultrasound, n = 24; 2. sham ultrasound, n = 25; Treatment provider: NR | Once every 2 weeks (ultrasound was given one per week) 10 weeks | 1. Pain: pain intensity; 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 1/13
Chen, L (2007)256 China | 70 | Male (%): 57.5% Mean age: 42 years | Patients with cervicogenic headache > 6 months without drug therapy in 3 months | 1. Spinal manipulation, n = 36; 2. TENS, n = 34; Treatment provider: NR | 20 to 30 minutes every 2 days 10 sessions in total | 1. Pain (numeric rating scale, NRS); 2. ROM; 3. ADVERSE EVENTS: no information reported | 7/13
Haas, M (2004)257 U.S. | 24 | Male (%): 18% Mean age: 40 years | Patients 18 years and older and uncomplicated chronic cervicogenic headaches for at least 3 months | 1. Spinal manipulation by chiropractors with 3-9 years experience, 3 sessions, n = 8; 2. Spinal manipulation by the same chiropractors, 9 sessions, n = 8; 3. Spinal manipulation by the same chiropractors, 12 sessions, n = 8; Co-intervention for all groups: massage and other treatments | 3, 9, or 12 sessions of manipulatio n were compared | 1. Pain intensity and number of headaches in past 4 weeks; 2. Neck pain; 3. Disability due to headache; 4. Disability due to neck pain; Immediate, short term and intermediate follow up | 7/13
Bokine, P (1995)258 U.S. | 126 | Male (%): | Patients 18 years and older and chronic cervicogenic headaches for at least 3 months | 1. Spinal manipulation by general practitioner, n = 70; 2. medication (Amitriptyline) by general practitioner, n = 56 | 20 minutes, twice a week 6 weeks | 1. Pain (0 – 5); 2. quality of life; 3. AE; Immediate, short term and intermediate follow ups | 1/13
Ouseley, BR (2002)259 U.K | 11 | Male (%): 35% Mean age: 40 years | Patients with chronic headache (tension type) | 1. Spinal manipulation by clinician with at least 3 years experience, n = 5; 2. Spinal mobilization, n = 6 | Maximum of 8 sessions 4 weeks | 1. Pain (NRS, 0 – 10); 2. Neck disability index (NDI); 3. ADVERSE EVENTS: no information reported | 5/13
Nilsson, N (1997)260 Denmark | 54 | Male (%): 43% Mean age: NR (median 37 years) | Patients 20 to 60 years with headache >= 5 days per month for at least 3 months in occipital region | 1. Spinal manipulation by registered chiropractor, n = 28; 2. massage by registered chiropractor, n = 25 | 2-week observation period, followed by six sessions of SM 3 weeks | 1. Pain (VAS headache); 2. change in medication use; Immediate post treatment follow up | 7/13
Whittingham, W (2001)261 Australia | 105 (cross over design) | Male (%): 41% Mean age: 40 years | Patients with cervicogenic headache for longer than 6 months, headache in occipital region | 1. Spinal manipulation by experienced chiropractor; 2. Placebo manipulation by experienced chiropractor; 3. No treatment | 2- week observation period SM, placebo SM, and no treatment 3 weeks each 9 weeks trial duration | 1 Pain intensity (head and neck); 2 Pain frequency; 3 change in medication use; 3 ADVERSE EVENTS: no information reported; Data for 1^st^ phase is used | 8/13
Sterling, M (2001)262 Canada | 30 (cross over design) | Male (%): 50% Mean age: 36 years | Patients with mid to lower cervical spine pain of insidious onset, greater than 3 months duration | 1. Spinal mobilization, n = 10; 2. Sham mobilization, n = 10; 3. no treatment, n = 10; Treatment provider: NR | Once per treatment | 1. Pain (VAS); 2. Pressure Pain Threshold; 3. EMG activity; 4. ADVERSE EVENTS: no data reported | 7/13

Table 2.13 Neck Pain - Manipulation & Mobilization – Mixed - Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Fernandez-de-las-Penas, C (2004)263 Spain | 88 | % male: 45 Mean age: 31.2 yrs | Suffering from neck and head pain due to whiplash injury of less than 3 months and classified in grades II and III | 1. Dorsal Manipulation + Physiotherapy, n = 44; 2. Physiotherapy, n = 44; Treatment provider: NR | 15 sessions | 1. Pain: VAS (0-100); 2. ADVERSE EVENTS: no harms reported; Data measured at end of treatment sessions | 6/13
Coppieters, M (2003)264 Belguim | 20 | Male (%): 40% Mean age: 48.5 years | Patients with cervicobrachial pain of 2 – 6 months duration due to neurogenic disorders | 1. cervical mobilization by trained manipulative therapist, n = 10; 2. Ultrasound, n = 10 | Single treatment session of 3 repetitions | 1. Pain perception during NTPT1 - neural tissue provocation testing for median nerve | 5/13

Table 2.14 Neck Pain - Manipulation & Mobilization - Mixed - Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Population (Gender, Age) Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Hurwitz, E (2002)265 California, US | 336 | % male: 31.2 Mean age: 45.7 yrs | 18-70 years belonging to a health maintenance organization; seeking care between Feb 9/98- June 30/00 presenting with NP; not having received treatment for NP in past mo Unknown ( | 1. Manipulation by a chiropractor, n = NR; 2. Manipulation with heat, n = NR; 3. Manipulation with Electrical Muscle stimulation, n = NR; 4. Manipulation with heat and electrical muscle stimulation, n = NR; 5. Mobilization, n = NR; 6. Mobilization with heat, n = NR; 7. Mobilization with electrical muscle stimulation, n = NR; 8. Mobilization with heat and electrical stimulation, n = NR | 4 weeks | 1. Pain: 11-pt NRS most severe pain in last week; average pain intensity during past week-11-pt NRS; 2. Disability: NDI (0-50); 3. Quality of Life: SF-36 physical function, physical role; 4. Work: Job Demands Questionnaire; 5. ADVERSE EVENTS: Transient minor discomfort; Data measured at 4 weeks, 3 and 6 mo, and 1 yr | 7/13
Cassidy, J (1992)266 Canada | 100 | Male (%): NR Mean age: 36 years | Mechanical neck pain with radiation into the trapezius muscle | 1. manipulation by an experienced clinician, n = 52; 2. mobilization by an experienced clinician, n = 48 | Single treatment session | 1. Pain: numerical rating scale (0 – 100)- lower values better; 2. Physical measures: range of motion; 3. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 6/13
Martinez-Segura, R (2006)267 Alicante, Spain | 71 | % male: 36.7 Mean age: 37 yrs | 18 yrs or older with mechanical NP of at least 1 mo; referred by primary care physician to private physical therapy and osteopathy clinic | 1. Cervical HVLA by a therapist with more than 5 years experience, n = 34; 2. Control (manual mobilization) by the same therapist, n = 37 | One treatment | 1. Pain: VAS NP at rest (0-100 cm); 2. Disability: Cervical range of motion; 3. ADVERSE EVENTS: no harms reported; Data measured at end of treatment | 6/13
Haas, M (2003)268 Portland, US | 104 | % male: 37 Mean age: 42.6 | 18 years and older; minimum pain level of 10 on 100mm VAS who had not received cervical manipulation in preceding 48 hrs | 1. Manipulation-Supine HVLA of cervical spine by 2 chiropractors, one with 20 years experience and the other with 2 years, n = 52; 2. Sham Manipulation generated by computer algorithm by the same chiropractors, n = 52 | One treatment | 1. Pain: VAS 100 mm for NP; 2. Disability: VAS 100 mm for Neck stiffness; 3. ADVERSE EVENTS: no harms reported; Data measured at end of treatment and 3 mo | 8/13
Vernon, H (1990)269 Canada | 9 | Male% = 67 Mean age: 38 years | Mechanical neck pain (not defined) Mixes population, majority acute and sub-acute | 1. manipulation, n = 5; 2. mobilisation, n = 4; Treatment provider: NR | Single treatment session | 1. Pain: pressure pain threshold (kg/cm^2^) a t 4 tender points; 2. ADVERSE EVENTS: no harms reported; Measured immediately post treatment | 6/13
Cleland, JA (2007)270 US | 104 | % male: 45 Mean age: 43.2 yrs | Subjects aged 18-60 yrs with primary complaint of neck pain, and baseline NDI=>10% | 1. TS-M/M with thrust by a clinician with 9.7 (1-19) years experience, n= 30; 2. TS-M/M without thrust by the same clinician, n= 30 | Single treatments session; duration: 3 min | 1. Pain: NPR; 2. Disability: NDI; 3. Well-being: GROC; 4. ADVERSE EVENTS: no harms reported | 7/13
Strunk, R (2007)271 U.S. | 6 | Male (%): 83% Mean age: 48 years | Patients 20- 65 years with primary complaint of mechanical neck pain for at least 4 weeks | 1. Cervical manipulation by experienced licensed chiropractor, n = 3; 2. Thoracic and sacroiliac joint manipulation by experienced licensed chiropractor, n = 3 | 4 sessions 2 weeks | 1. Pain (VAS 0 – 100 mm); 2. Neck Disability; 3. ADVERSE EVENTS: no information reported; Immediate post treatment follow up | 6/13
Kanlayanaphotporn, R (2009)272 Thailand | 60 | Male (%): 40% Mean age: 43 years | Patients with mechanical neck pain provoked by neck movements or sustained pressure, unilaterally distributed for at least 1-week duration; and VAS score of >20 at rest | 1. Ipsilateral unilateral posteroanterior mobilization by physical therapist, n = 30; 2. Random mobilization by physical therapist, n = 30 | Single treatment | 1. Pain (VAS 0 – 100); 2. Neck disability; 3. ADVERSE EVENTS: no AE occurred | 11/13
Brodin, H (1983)273 Sweden | 63 | Male (%): NR Mean age: NR | Patients 27 to 60 years; condition suitable for manual therapy | 1. Mobilization by physiotherapist, n = 23; 2. Sham mobilization, n = 17; 3. Medication and information, n = 23; Cointervention in group 1 and 2: medication and information | 3 times per week 3 weeks | 1. Pain; 2. Mobility; Immediate and short term follow ups | 3/13

Table 2.15 Neck Pain - Manipulation & Mobilization - Unknown - Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Cilliers, K (1998)274 South Africa | 30 | Male (%): 40 (53 vs. 27) Mean age: 31 years | Cervical facet syndrome and neck pain | 1. manipulation (top segment adjustment) by a chiropractor, n =15; 2. manipulation (bottom segment adjustment) by a chiropractor, n = 15 | 8 treatments 4 weeks | 1. Pain: McGill pain questionnaire; 2. Disability: neck disability index; 3. Physical Measures: range of motion; Data measured at 4 weeks and 3 mo | 3/13
Egwu, MONTHS (2008)275 Nigeria | 96 | Male (%): 100% Mean age: 44 years | Patients 40 – 50 years old with cervical spondylosis and severe neck pain with onset of within 6 weeks at time of entry to the trial | 1. posteroanterior unilateral manipulation, n = 24; 2. Antero-posterior unilateral manipulation, n = 24; 3. Cervical oscillatory rotation, n = 24; 4. Transverse oscillatory pressure, n = 24; Treatment provider : therapists | 3 times per week until cured up to 4 weeks 4 weeks | 1. Pain (pain free patients at the end of treatment); 2. ADVERSE EVENTS: no information provided | 1/13

Table 2.16 Neck Pain - Manipulation & Mobilization - Unknown - Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
van Schalkwyk, R (2000)276 South Africa | 30 | Male (%): 67 Mean age: 30 years | Mechanical NP with lateral fixation | 1. manipulation on the ipsilateral side, n = 15; 2. manipulation on the contralateral side, n = 15; Treatment provider: NR | 10 sessions 4 weeks | 1. Pain: numerical pain rating 101; McGill short form pain questionnaire; 2. Disability: Neck disability index; 3. Range of motion; Measured immediately post intervention and at 1 month | 1/13
Krauss, J (2008)277 Oakland, US | 32 | Male (%): 22 (14 vs. 30) Mean age: 35 years | Non-specific neck pain (C4 – C7) aggravated by active rotation | 1. Manipulation by an orthopaedic manual physical therapist, n 22; 2. No treatment by the same therapist, n = 10 | Single treatment session | 1. Pain: Faces pain scale measuring pain at end of active R, L, and bilateral rotation in R and L component; Immediately post intervention | 9/13
Parkin-Smith, G (1998)278 South Africa | 30 | % male: 62.5 Mean age: 35.4 yrs | Patients between 16-60 yrs; negative Wallenberg’s test; mechanical NP without neurological or vascular deficit; no medication for NP during study | 1. Cervical Manipulation by a chiropractor, n = 13; 2. Cervical and Upper Thoracic Manipulation, n = 17 | 6 treatment sessions 3 weeks | 1. Pain: NPRS (0-100); 2. Disability: CMCC NDI (0-100); 3. ADVERSE EVENTS: no harms reported; Data measured at 3 weeks | 6/13
Metcalfe, S (2006)279,280 Canada | 67 | % male: 23.9 Mean age: 37 years | With NP or headaches | 1. Manipulation by a physical therapist, n = 46; 2. Control-Manipulation by the same therapist, n = 26 | One treatment | 1. Physical Measures: Neck muscle strength; 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 4/13

Table 2.17 Neck Pain – Spinal Manipulation – Chronic – Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Population (Gender, Age) Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Bischoff, A (2003)255 NR | 49 | Male (%): NR Mean age: NR | Non-specific neck pain Chronic | 1. osteopathic intervention + sham ultrasound, n = 24; 2. sham ultrasound, n = 25; Treatment provider NR | Once every 2 weeks (ultrasound was given one per week) 10 weeks | 1. Pain: pain intensity; 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 1/13

Table 2.18 Neck Pain – Spinal Manipulation – Mixed – Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Korthanis-de Bos, I (2003)281,282 Netherlands | 183 | % male: 39 Mean age: 45.5 yrs | Physiotherapy or manual therapy for NP in previous 6 mo, surgery of neck or specific cause of NP Unknown (mix) | 1. Manual therapy, by 6 registered manual therapists who had followed a 3 years curriculum in manual therapy after training in physiotherapy, n = 60; 2. Physiotherapy, by 5 physiotherapists, n = 59; 3. General Practitioner care, n = 64 | 1. maximum of 6 sessions; 2. maximum of 12 sessions; 6 weeks; 3 one session | 1. Pain: Perceived recovery-6-pt scale; mean pain during preceding week-11-pt scale; 2. Disability: NDI; 3. Work: Absenteeism from paid, unpaid work due to NP; 4. Utility of conventional care: Euro Quality of Life; N of patient taking prescription drugs; N of visits to general practice; N of sessions of manual therapy, physiotherapy; help from others; N of outpatient visits to medical specialist care; 5. Cost: 52-week cost diary-Direct, Indirect costs; 6. ADVERSE EVENTS: minor benign short term, reaction; increase in NP; Data measured at 3 months and 1 year | 7/13

Table 2.19 Neck Pain – Spinal Manipulation – Unknown – Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Cleland, J (2004)283 United States | 68 | Male % = NR Age range: 18 – 60 years | Mechanical neck pain NR | 1. thoracic spine manipulation, n = NR; 2. sham, n = NR; Treatment provider NR | Single treatment session | 1. Pain: VAS; 2. ADVERSE EVENTS: no harms reported; Measured immediately post intervention | 2/13

Table 2.20 Neck Pain- Spinal Mobilization- Acute – Specific Pain –

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Kongsted, A (2007)284 Denmark | 458 | % male: 28.3 Mean age: 33.3 years | 18-65 years with acute whiplash associated disorder Acute | 1. Mobilization program, by one physiotherapist, n = 149; 2. Information and advice, by research nurse, n = 153; 3. Cervical collar (immobilization) applied by project nurse at initial phase and active mobilization as group 1 for rest of study period | 1. Maximum twice daily for 6 weeks; 2. one session; 3. 2 weeks collar + 4 weeks twice daily mobilization | 1. Pain: neck and headache VAS (0-10)-lower better; 2. Disability: Neck Disability Scale (0-30) lower better; SF-36 Physical health summary; 3. Work: Subjects with affected work disability, ability; 4. Utility of conventional care: analgesics used; any other treatments other than study intervention; 5. ADVERSE EVENTS: no harms reported; Data measured at 1 year | 5/13

Table 2.21 Neck Pain- Spinal Mobilization- Acute – non-Specific Pain

Table 2.22 Neck Pain - Massage - Acute - Specific Pain – No studies

Table 2.23 Neck Pain - Massage - Acute - Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Blikstad, A (2007)285 England | 45 | % male: 44.7 Mean age: 23.8 yrs | Between 18-55 yrs; Non-specific unilateral or bilateral NP of 4-12 weeks and at least 4 on an 11 pt NRS Sub-acute | 1. Activator Trigger Point Therapy (AtrPT) by a clinician, n = 15; 2. Myofascial band therapy (MBT), n = 15; 3. Sham Ultrasound (SUS), n = 15 | One treatment session | 1. Pain: NRS (0-10); PPT (kg/cm^2^) (pressure algometer); 2. ADVERSE EVENTS: no harms reported; Data measured at end of treatment | 10/13

Table 2.24 Neck Pain - Massage - Chronic- Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Yagci, N (2004)286 Turkey | 40 | % male: 25 Mean age: 30.9 years | Diagnosis of myofascial pain syndrome for at least 6 mo Chronic | 1. Vapo-coolant spray and stretch technique, n = 20; 2. Connective tissue massage, n = 20; Treatment provider: NR | 3 treatments/day | 1. Pain: VAS; Pain threshold; Pain tolerance; 2. Disability: Number of trigger points; 3. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 2/13
Irnich D (2001)205,206 Germany | 177 | % male: 34 Mean age: 52.4 years | Patients with chronic NP (>1 mo) and painful restriction of cervical spine mobility, not received treatment two weeks before the study | 1. Acupuncture by experienced and licensed acupuncturists, n = 56; 2. Massage by experienced physiotherapists, n = 60; 3. Sham Laser, n = 61 | 5 sessions 3 weeks | 1. Pain: VAS; PPT; 2. Quality of Life: SF-36: Role physical, Pain Index; 3. ADVERSE EVENTS: mild reactions (slight pain, sweating, LBP); Data measured at 1 and 3 weeks, and 3 months | 4/13
Cen, S (2003)287 California, US | 31 | % male: 25.8 Mean age: 48.7 years | NP and loss in ROM for more than 1 year | 1. Traditional Chinese Therapeutic Massage (TCTM) by a licensed acupuncturist, n = 10; 2. Exercise Program, n = 10; 3. Control-no treatment, n = 11 | 1. 18 sessions over 6 weeks; 2. assuming one session | 1. Pain: Northwick Park Neck Pain Questionnaire (0-100)-higher score; 2. Neck flexibility; 3. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 4/13

Table 2.25 Neck Pain - Massage - Chronic - Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Zaproudina, N (2007)288 Finland | 102 | % male: 34.2 Mean age: 41.5 years | Patients with chronic N-S NP, aged 28-50 years | 1. Traditional bone-setting by an experienced Finnish bone setters, n = 35; 2. Physiotherapy by a registered therapist, n = 34; 3. Massage by a physiotherapist, n = 33 | 5 sessions | 1. Pain: NP VAS; 2. Disability: NDI; 3. ADVERSE EVENTS: no harms reported; Data measured at 3 months and 1 year
Sherman, K.J (2009)289 US | 64 | % male: 31.2 Mean age: 57 years | 20-64 years who had received primary care for NP at least 3 months prior to the study | 1. Massage by massage therapists, n = 32; 2. Self-care-book, n = 32 | Up to 10 massage treatments 10 weeks | 1. Disability: NDI; 2. Pain: 11-pt(0-10) NRS; SF-36 physical and mental health component; 3. Quality of Life: global improvement; 4. Utility of health care: questions regarding use of other treatments during study period; use of medication in last week; 5. ADVERSE EVENTS: increased soreness, discomfort or pain during treatment; Data measured at 4, 10 and 26 weeks | 8/13

Table 2.26 Neck Pain - Massage - Mixed - Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Population (Gender, Age) Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Lin, M (2004)234 China | 100 | % male: 65 Mean age: 46 years | Cervical spondylopathy of nerve root type, aged 25-76 years Acute-Chronic | 1. Needle scalpel combined with Massage therapy, n = 50; 2. Simple Massage therapy, n = 50; Treatment provider: NR | 21 treatments 3 months | 1. Quality of Life: Cure; 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 3/13
Yi-zhen (2005)290 China | 52 | % male: 55.8 Mean age: NR | Diagnosis of cervical spondylopathy owing to first attack or repeated attacks | 1. Traction and Massage, n = 26; 2. Traction only, n = 26; Treatment provider: NR | One treatment/day 5 days/course 1-2 courses | 1. Pain: treatment effect rating scale; 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 1/13
Fernandes-de-las-Penas, C (2005)291 Spain | 40 | % male: 42.5 Mean age: 28.7 years | At least 18 years old with mechanical NP for at least 2 weeks | 1. Ischemic compression technique, n = 20; 2. Transverse friction massage, n = 20; Treatment provider: NR – vaguely stated as “therapist” | NR | 1. Pain: PPT(pressure pain threshold); VAS(2.5 kg/cm^2^ of pressure on MTrP); 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 7/13
Zhang, W (2005)240 China | NR | % male: 65.63 Mean age: NR | Cervical spondylopathy | 1. Acupuncture + Massage / Manipulation n = 64; 2. Massage (Control) n = 32; Treatment provider: NR | 3x/week, for 3 weeks | NR | 0/13
Fernandes-de-las-Penas, C (2005)291 Spain | 40 | % male: 42.5 Mean age: 28.7 years | At least 18 years old with mechanical NP for at least 2 weeks NR | 1. Ischemic compression technique by physiotherapist, n = 20; 2. Transverse friction massage, n = 20 | NR | 1. Pain: PPT(pressure pain threshold); VAS(2.5 kg/cm^2^ of pressure on MTrP); 2. ADVERSE EVENTS: no harms reported; Data measured immediately post intervention | 7/13

Table 2.27 Neck Pain - Massage - Mixed - Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Gemmell, H (2007)292 England | 45 | % male: NR Mean age: 23.5 yrs | Between 18-55 yrs with non-specific NP of at least 30mm on a VAS, and upper trapezius TP and decreased cervical lateral flexion to the opposite side of the active upper trapezius TP | 1. Ischemic Compression (IC) by a 4^th^ year chiropractic student trained by a chiropractor with 28 years clinical practice, n = 15; 2. Trigger Point Pressure Release (TrPPR), n = 15; 3. Sham Ultrasound (SUS), n = 15 | One treatment session | 1. Pain: VAS (0-100); Pressure Pain Threshold (PPT-kg/cm^2^); 2. ADVERSE EVENTS: no harms reported; Data measures at end of treatment session | 9/13
Hemmila, H (2005)293 | 42 | Male (%): 30% Mean age: 46.5 | Patients 18 - 64 years; diagnosis of tension neck syndrome for at least one month | 1. Massage by experienced folk healer, n = 22; 2. Control: neither offered nor denied any treatments, n = 20 | 5 sessions, 30 minutes each 5 weeks | 1. Pain (million scale adapted for neck pain); 2. Pain drawings; 3. Health care utilization; 4. Sick leaves due to neck pain; – Cervical ROM; – self rated improvement of neck pain; measured at immediate, short term, intermediate and long term follow ups | 5/13

Table 2.28 Neck Pain - Massage - Unknown - Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Hanten, W (1997)294 U.S. | 60 | Male (%): 30% Mean age: 30 years | Patients with one or more active or latent cervical and or scapular trigger points without any known orthopaedic cardiovascular or neurological conditions | 1. Massage: occipital release (traction), n = 20; 2. Massage: head retraction/retraction-extension, n = 20; 3. No treatment, n = 20; Treatment provider: NR (“Examiner”) | One treatment session | 1. Pain: Pressure Pain Threshold (PPT-kg/cm^2^) | 5/13
Hou CR (2002)295 Taiwan | 40 | Male (%): NR Mean age: 43 years | clinically active, palpable MTrPs in a single side or both sides | 1. ischemic compression to pain threshold, 60 sec, n =8; 2. ischemic compression to pain threshold, 90 Sec, n =8; 3. ischemic compression to Average of Pain Threshold and Pain Tolerance, 30 sec, n= 8; 4. ischemic compression to Average of Pain Threshold and Pain Tolerance, 60 sec, n= 8; 5. ischemic compression to Average of Pain Threshold and Pain Tolerance, 90 sec, n=8; All treatments provided by an experienced physical therapist | One treatment session | 1. Pain: VAS (0-10); | 2/13
Fryer (2005)296 Australia | 37 | Male (%): 32.4 Mean age: 23.1 years | presence of latent MTrPs in the upper trapezius muscle | 1. myofascial release, n = 20; 2. sham myofascial release, n = 17; Treatment provider: NR | One treatment session | 1. Pain: PPT | 5/13

Table 2.29 Neck Pain - Massage - Unknown - Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Meseguerm, AA (2006)297 Spain | 54 | Male (%): 30% Mean age: 38 years | Patients 19-41 years old with mechanical neck pain, tender point in the upper trapezius muscle either on the left or right side. (mechanical pain defined as a generalized neck and or shoulder pain with mechanical characteristics including symptoms provoked by maintained neck postures by movement or by palpation of the postures by movement or by palpation of cervical muscles) | 1. manipulation (stain/counter strain), n = 18; 2. modified manipulation (stain/counter strain), n = 18; 3. no treatment, n= 18; Treatment provider: NR (clinician with experience in management of mechanical NP) | One treatment session | 1. Pain: VAS (0-10); Pressure Pain Threshold (PPT-kg/cm^2^) | 6/13

## Thoracic Pain

Table 3.1 Thoracic Pain – Manipulation – Unknown – Non-Specific Pain

Study ID Year Country | Total sample size | Population (Gender, Age) | Eligibility | Randomized Groups (no. of patients) | Frequency and Treatment duration | Outcomes and post-treatment follow-up | Quality score
Schiller, L (2001)298 | 30 | % male: 47 Mean age: NR | Subjects 16-60 years with diagnosis of mechanical thoracic spine pain | 1. Experimental group, n = 15; 2. Non-functional ultrasound, n = 15; Treatment provider NR | Maximum of 6 treatments 2-3 weeks | 1. Pain: McGill; NRS-101; 2. Disability: OSW; Data measured at end of treatment and 1 month | 2/13

## Reference List

1 Huang S, Zhan H, Shi Y. Clinical lumbar function-recovering effect of different electroacupuncture points on lumbar intervertebral disc herniation. [Chinese]. Chinese J of Rehab Med. 2006;21(6):497-500.
2 Lai YZ, Zhuang LX, Zhuang ZJ, et al. [Clinical observations on needling xi-cleft points as a main treatment for the acute stage of lumbar intervertebral disc protrusion]. Shanghai J Acupunct Moxibustion. 2004;23(9):22-4.
3 Long WJ. Acupuncture treatment of acute lumbar sprain: a controlled study in 238 patients. Int J Clin Acupunct. 2000;11(1):61-4.
4 Kennedy S, Baxter GD, Kerr DP, et al. Acupuncture for acute non-specific low back pain: a pilot randomised non-penetrating sham controlled trial. Complement Ther Med. Jun. 2008;16(3):139-46. [pmid: 18534326].
5 Eisenberg DM, Post DE, Davis RB, et al. Addition of choice of complementary therapies to usual care for acute low back pain: a randomized controlled trial. [see comment]. Spine. Jan 15. 2007;32(2):151-8. [pmid: 17224808].
6 Cao W, Wang J. Curative effect of acute lumbago with different acupuncture and moxibustion methods. Int J Clin Acupunct. 2001;12(1):21-9.
7 Araki S, Kawamura O, Mataka T, et al. [Randomized controlled trial comparing the effect of manual acupuncture with sham acupunture ofr acute low back pain]. J Japan Soc Acupunct Moxibustion. 2001;51(3):382.
8 Kittang G, Melvaer T, Baerheim A. [Acupuncture contra antiphlogistics in acute lumbago].[see comment]. [Norwegian]. Tidsskrift for Den Norske Laegeforening. Apr 20. 2001;121(10):1207-10. [pmid: 11402745].
9 Itoh K, Katsumi Y, Kitakoji H. Trigger point acupuncture treatment of chronic low back pain in elderly patients--a blinded RCT. Acupunct Med. Dec. 2004;22(4):170-7. [pmid: 15628774].
10 Ceccherelli F, Rigoni MT, Gagliardi G, et al. Comparison of superficial and deep acupuncture in the treatment of lumbar myofascial pain: a double-blind randomized controlled study. Clin J Pain. May. 2002;18(3):149-53. [pmid: 12048416].
11 Gunn CC, Milbrandt WE, Little AS, et al. Dry needling of muscle motor points for chronic low-back pain: a randomized clinical trial with long-term follow-up. Spine. May. 1980;5(3):279-91. [pmid: 6446774].
12 Haake M, Muller HH, Schade-Brittinger C, et al. German Acupuncture Trials (GERAC) for chronic low back pain: randomized, multicenter, blinded, parallel-group trial with 3 groups. [erratum appears in Arch Intern Med. 2007 Oct 22;167(19):2072]. Arch Intern Med. Sep 24. 2007;167(17):1892-8. [pmid: 17893311].
13 Inoue M, Kitakoji H, Ishizaki N, et al. Relief of low back pain immediately after acupuncture treatment--a randomised, placebo controlled trial. Acupunct Med. Sep. 2006;24(3):103-8. [pmid: 17013356].
14 Witt CM, Jena S, Selim D, et al. Pragmatic randomized trial evaluating the clinical and economic effectiveness of acupuncture for chronic low back pain. Am J Epidemiol. Sep 1. 2006;164(5):487-96. [pmid: 16798792].
15 Itoh K, Katsumi Y, Hirota S, et al. Effects of trigger point acupuncture on chronic low back pain in elderly patients--a sham-controlled randomised trial. Acupunct Med. Mar. 2006;24(1):5-12. [pmid: 16618043].
16 Brinkhaus B, Witt CM, Jena S, et al. Acupuncture in patients with chronic low back pain: a randomized controlled trial. [see comment]. Arch Intern Med. Feb 27. 2006;166(4):450-7. [pmid: 16505266].
17 Giles LG, Muller R. Chronic spinal pain: a randomized clinical trial comparing medication, acupuncture, and spinal manipulation. [see comment]. Spine. Jul 15. 2003;28(14):1490-502. [pmid: 12865832].
18 Sator-Katzenschlager SM, Scharbert G, Kozek-Langenecker SA, et al. The short- and long-term benefit in chronic low back pain through adjuvant electrical versus manual auricular acupuncture. [see comment]. Anesth Analg. 2004;98(5):1359-64. [pmid: 15105215].
19 Chu J, Yuen KF, Wang BH, et al. Electrical twitch-obtaining intramuscular stimulation in lower back pain: a pilot study. [see comment]. Am J Phys Med Rehabil. Feb. 2004;83(2):104-11. [pmid: 14758296].
20 Ceccherelli F, Gagliardi G, Barbagli P, et al. [Correlation between the number of sessions and therapeutical effect in patients suffering from low back pain treated with acupuncture: a randomized controlled blind study]. [Italian]. Minerva Medica. Aug. 4 Suppl 1. 2003;94:39-44. [pmid: 15108610].
21 Meng CF, Wang D, Ngeow J, et al. Acupuncture for chronic low back pain in older patients: a randomized, controlled trial. Rheumatology. Dec. 2003;42(12):1508-17. [pmid: 12890859].
22 Kerr DP, Walsh DM, Baxter D. Acupuncture in the management of chronic low back pain: a blinded randomized controlled trial. Clin J Pain. Nov. 2003;19(6):364-70. [pmid: 14600536].
23 Yeung CK, Leung MC, Chow DH. The use of electro-acupuncture in conjunction with exercise for the treatment of chronic low-back pain. J Altern Complement Med. Aug. 2003;9(4):479-90. [pmid: 14499023].
24 Molsberger AF, Mau J, Pawelec DB, et al. Does acupuncture improve the orthopedic management of chronic low back pain--a randomized, blinded, controlled trial with 3 months follow up. [see comment]. Pain. Oct. 2002;99(3):579-87. [pmid: 12406534].
25 Leibing E, Leonhardt U, Koster G, et al. Acupuncture treatment of chronic low-back pain -- a randomized, blinded, placebo-controlled trial with 9-month follow-up. Pain. Mar. 2002;96(1-2):189-96. [pmid: 11932074].
26 Carlsson CP, Sjolund BH. Acupuncture for chronic low back pain: a randomized placebo-controlled study with long-term follow-up. Clin J Pain. Dec. 2001;17(4):296-305. [pmid: 11783809].
27 Cherkin DC, Eisenberg D, Sherman KJ, et al. Randomized trial comparing traditional Chinese medical acupuncture, therapeutic massage, and self-care education for chronic low back pain. Arch Intern Med. Apr 23. 2001;161(8):1081-8. [pmid: 11322842].
28 Grant DJ, Bishop-Miller J, Winchester DM, et al. A randomized comparative trial of acupuncture versus transcutaneous electrical nerve stimulation for chronic back pain in the elderly. Pain. Jul. 1999;82(1):9-13. [pmid: 10422654].
29 Lehmann TR, Russell DW, Spratt KF. The impact of patients with nonorganic physical findings on a controlled trial of transcutaneous electrical nerve stimulation and electroacupuncture. Spine. Sep. 1983;8(6):625-34. [pmid: 6228019].
30 Macdonald AJ, Macrae KD, Master BR, et al. Superficial acupuncture in the relief of chronic low back pain. Ann R Coll Surg Engl. Jan. 1983;65(1):44-6. [pmid: 6218776].
31 Mendelson G, Selwood TS, Kranz H, et al. Acupuncture treatment of chronic back pain. A double-blind placebo-controlled trial. Am J Med. Jan. 1983;74(1):49-55. [pmid: 6217745].
32 Coan RM, Wong G, Ku SL, et al. The acupuncture treatment of low back pain: a randomized controlled study. Am J Chinese Med. 1980;8(1-2):181-9.
33 Mendelson G, Kidson MA, Loh ST, et al. Acupuncture analgesia for chronic low back pain. Clin Exp Neurol. 1978;15:182-5. 1978.:182-5. [pmid: 158752].
34 Fu ZH, Chen XY, Lu LJ, et al. Immediate effect of Fu's subcutaneous needling for low back pain. Chin Med J. Jun 5. 2006;119(11):953-6. [pmid: 16780777].
35 Lian N, Liu J-B, Torres F, et al. Improvement of dermal needle and body acupuncture on pain due to lumbar strain and hyperplastic spondylitis. Chinese J Clin Rehab. 2005;9(42):161-3.
36 Li N, Wu B, Wang C-W. Comparison of acupuncture-moxibustion and physiotherapy in treating chronic non-specific low back pain. [Chinese]. Chinese J Clin Rehab. 2005;9(2):186-7.
37 Wang B-X, La J-L. Therapeutic effects of electro-acupuncture and diclofenic on herniation of lumbar intervertebral disc. Chinese J Clin Rehab. 2004;8(17):3413-5.
38 Hollisaz MT. Use of electroacupuncture for treatment of chronic sciatic pain. Internet J Pain Sypmtom Contr Palliat Care. 2006;(1):7p.
39 Takeda H, Nabeta T. [Randomized controlled trial comparing the effect of distal pint needling with local point needling for low back pain]. J Japan Soc Acupunct Moxibustion. 2001;51(3):411.
40 Sakai T, Tsukayama H, Amagai H, et al. [Controlled trial on acupuncture for lumbago]. J Japan Soc Acupunct Moxibustion. 1998;48(1):110.
41 Yu WH, Fan WM, Cai H, et al. Clinical and mechanical studies on treatment of lumbago by needing WEIZHONG (BL40) point. Chinese Acupunct Moxibustion. 1997;17(8):503-4.
42 Itoh K, Itoh S, Katsumi Y, et al. A pilot study on using acupuncture and transcutaneous electrical nerve stimulation to treat chronic non-specific low back pain. Complement Ther Clin Pract. Feb. 2009;15(1):22-5. [pmid: 19161950].
43 Yuan J, Purepong N, Hunter RF, et al. Different frequencies of acupuncture treatment for chronic low back pain: an assessor-blinded pilot randomised controlled trial. Complement Ther Med. Jun. 2009;17(3):131-40. [pmid: 19398066].
44 Cherkin DC, Sherman KJ, Avins AL, et al. A randomized trial comparing acupuncture, simulated acupuncture, and usual care for chronic low back pain. Arch Intern Med. May 11. 2009;169(9):858-66. [pmid: 19433697].
45 Hirota S, Itoh K, Katsumi Y. A controlled clinical trial comparing trigger point acupuncture with tender point acupuncture treatments for chronic low back pain: A pilot study on 9 elderly patients. J Japan Soc Acupunct Moxibustion. 2006;(56):67-85.
46 Tsui ML, Cheing GL. The effectiveness of electroacupuncture versus electrical heat acupuncture in the management of chronic low-back pain. J Altern Complement Med. Oct. 2004;10(5):803-9. [pmid: 15650469].
47 Thomas M, Lundberg T. Importance of modes of acupuncture in the treatment of chronic nociceptive low back pain. Acta Anaesthesiol Scand. Jan. 1994;38(1):63-9. [pmid: 8140876].
48 Kwon Y, Lee S, Lee C, et al. The short-term efficacy of acupuncture for chronic low back pain: randomized sham controlled trial. J Orient Rehab Med. 2007;17(2):123-32.
49 Inoue M, Ktakouji H, Ikeuchi R, et al. [Randomized controlled pilot study comparing acupuncture with sham acupunture for lumbago]. J Japan Soc Acupunct Moxibustion. 2000;50(2):356.
50 Chen MR, Wang P, Cheng G, et al. [Effect of warming needle moxibustion on pain threshold in the patient of sciatica]. [Chinese]. Zhongguo Zhen Jiu. Dec. 2005;25(12):831-3. [pmid: 16419700].
51 Liang SY. [Observation on therapeutic effect of tendon-muscle picking therapy on myofascitis of back]. [Chinese]. Zhongguo Zhen Jiu. Aug. 2008;28(8):621-2. [pmid: 18767591].
52 Tang HS. [Comparative observation of corresponding channel point selection for treatment of prolapse of lumbar intervertebral disc]. [Chinese]. Zhongguo Zhen Jiu. Aug. 2008;28(8):582-4. [pmid: 18767583].
53 She RP. [Observation on therapeutic effect of deeply needling Qiangji 4 points on prolapse of lumbar intervertebral disc]. [Chinese]. Zhongguo Zhen Jiu. May. 2008;28(5):341-4. [pmid: 18652325].
54 Mu JP, Cheng JM, Ao JB, et al. [Multiple central clinical test of electroacupuncture at Jiaji (EX-B 2) combined with laser needle-knife for treatment of lumbar disc herniation]. [Chinese]. Zhongguo Zhen Jiu. Aug. 2007;27(8):553-6. [pmid: 17853748].
55 Wu MQ. [Clinical observation on selection of acupoints on the same nerve segment for treatment of prolapxe of lumber intervertebral disc]. [Chinese]. Zhongguo Zhen Jiu. Jul. 2007;27(7):497-9. [pmid: 17722827].
56 He XW, Huang JH, Zeng LY. [Observation on the therapeutic effect of warming needle moxibustion on prolapse of lumbar intervertebral disc]. [Chinese]. Zhongguo Zhen Jiu. Apr. 2007;27(4):264-6. [pmid: 17585670].
57 Zhou YL, Zhang SQ, Sun GS, et al. [Clinical observation on ankle-three-needle for treatment of nerve root pain of prolapse of lumbar intervertebral disc]. [Chinese]. Zhongguo Zhen Jiu. Dec. 2006;26(12):847-50. [pmid: 17313003].
58 Zhang B-M, Wu Y-C, Shao P, et al. Electro-acupuncture therapy for lumbar intervertebral disc protrusion: A randomized controlled study. [Chinese]. J Clin Tissue Eng Res. 2008;12(2):353-5.
59 Huang G-F, Zhang H-X, Zhang T-F, et al. Time-dependent analgesic effect of electroacupuncture at Jiaji acupoint in patients with lumbar disc herniation and its intervention on related factors of plasma. [Chinese]. Chinese J Clin Rehab. 2006;10(43):1-6.
60 Wang N. Acupuncture plus traction therapy for lumbar intervertebral disc protrusion: Curative effect observation. [Chinese]. J Clin Tissue Eng Res. 2007;11(25):4945-8.
61 Li D-J, Wang J, Gao Q, et al. Complementary effect of traction rotatory manipulation of lumbar spine and silver needle heat conductive treatment on lumbar disc herniation. [Chinese]. Chinese J Clin Rehab. 2006;10(47):8-11.
62 Wang Y-Q, Tang L-X, Pan C-Q. Amelioration of ventral acupuncture therapy on the pain symptom in patients with lumbar disc herniation. [Chinese]. Chinese J Clin Rehab. 2005;9(38):122-3.
63 Guo W, Zhang H-J, Lin W-E. Effect of different acupuncture therapies in improving functional disturbance of waist and limbs in patients with multiple lumbar disc herniation at different stages. [Chinese]. Chinese J Clin Rehab. 2005;9(2):184-5.
64 Chen X. Comparative study on acupuncture needling methods for sciatica: Routine needling vs. Point-to-point penetration and deep puncture. Am J Acupunct. 1998;26(1):37-41.
65 Jia C, Jiang G-M, Liu D-G. Effect of deep acupuncture at jiaji acupoint and acupoint-injection on lumbar disc herniation and the influence on the levels of interleukins. [Chinese]. Chinese J Clin Rehab. 2004;8(17):3324-6.
66 Yuan X, Liu C, Wang J. Clinical observation of elongated needle treatment of lumbar intervertebral disc prolapse. Int J Clin Acupunct. 2006;15(2):81-3.
67 Ye Z. [Clinical studies on the treatment of lumbar intervertebral disc protrusion with a needle knife as the main method] [Chinese]. Shanghai J Acupunct Moxibustion. 2004;23(2):11-2.
68 Ding XIY. [Clinical observations on the treatment of intervertebral disc protrusion with contralateral acupuncture]. Shanghai J Acupunct Moxibustion. 2002;21(4):24.
69 Zhang D-W, Liang X-F, Wang Q-J. [Clinical research on the treatment of lumbar intervertebral disc protrusion by the combination of acupuncture and massage]. Shanghai J Acupunct Moxibustion. 2002;21(2):22.
70 Zhang Z. [Observations on the curative effect of acupuncture and massage on lumbar intervertebral disc protrusion]. Shanghai J Acupunct Moxibustion. 2002;21(3):15.
71 Ye D, Zhu H. [Treat lumbar intervertebral disc protrusion( (LIDP) by electric acupuncture traction and tuina in different stages]. J Zhejiang Coll Trad Chinese Med. 2002;26(3):60.
72 Chen Xa. [Dynamic b-ultrasonographic observation of the treatment of 80 patients with lumbar intervertebral disc prolapse by acupuncture-moxibustion plus three-palm massage]. Shanghai J Acupunct Moxibustion. 2001;20(6):14.
73 Yao Z. Observations on the curative effect of acupuncture and moxibustion on lumbar intervertebral disc protrusion] [Chinese]. Shanghai J Acupunct Moxibustion. 2007;26(2):25-6.
74 Chen XY. Observations on the efficacy of deep acupuncture of Jiaji points for treating lumbar intervertebral disc protrusion] [Chinese]. Shanghai J Acupunct Moxibustion. 2007;26(3):21-2.
75 Zeng YF. [Clinical observations on the treatment of 67 lumbar intervertebral disc protrusions by abdomen acupuncture] [Chinese]. Shanghai J Acupunct Moxibustion. 2007;26(9):16-7.
76 Zhong B. Treatment of lumbar intervertebral disc protrusion by abdominal acupuncture plus traction] [Chinese]. Shanghai J Acupunct Moxibustion. 2006;25(6):19-20.
77 Qu Y, Mei XD, Qu H. [Control observation of therapeutic effects on syndrome of the 3rd lumbar transverse process with thick silver warming needling and electric acupuncture][Chinese]. World J Acupunct-Moxibustion. 2006;16(3):19-22.
78 Ye L, Hu YM, Zhang SL. Clinical study on treatment of prolapse of lumbar intervertebral disc with hypodermic catgut embedding therapy] [Chinese]. Chinese Acupunct Moxibustion. 2004;24(4):245-7.
79 Wang Y. Point-through-point acupuncture treatment of 66 patients with third lumbar vertebra transverse process syndrome] [Chinese]. Shanghai J Acupunct Moxibustion. 2004;23(2):9-10.
80 Zhou ZT. Observations on the effect of abdominal acupuncture in treating 42 cases of lumbar intervertebral disc protrusion] [Chinese]. Shanghai J Acupunct Moxibustion. 2004;23(2):13-4.
81 Cui J, Xiang K, Liang YY. Scalp acupuncture and massage for treatment of prolapse of lumbar intervertebral disc and effects on immune functions] [Chinese]. Chinese Acupunct Moxibustion. 2004;24(7):445-8.
82 Wu Y, Liao J, Li Q. [Clinical observation on abdominal acupuncture for treatment of 114 cases of prolapse of lumbar intervertebral disc] [Chinese]. Chinese Acupunct Moxibustion. 2004;24(11):750-2.
83 Zhu Q, Li SL, Min XJ. [Clinical study on treatment of prolapse of lumbar intervertebral disc by acup-moxibustion combined with autonomic traction][Chinese]. Chinese Acupunct Moxibustion. 2003;23(10):571-3.
84 Zhang HL. [A randomized controlled trial of electroacupuncture and traction for treatment of nerve-root type cervical spondylosis][Chinese]. Chinese Acupunct Moxibustion. 2003;23(11):637-9.
85 Zhou Y. [Observation of the effectiveness of prolapse of lumbar intervebral disc treated by warm needling insert Jiaji points](in Chineses). Shanghai J Acupunct Moxibustion. 1998;17(2):25.
86 Xia FX. [41 cases of prolapse of lumbar intervertebral disc treated by complex treatment] [Chinese]. Shanghai J Acupunct Moxibustion. 1997;16(5):17.
87 Li Q, Shang W. The effect of acupuncture plus cupping on 78 cases with lumbago. Hebei Chinese Trad Med. 1997;19(5):28.
88 Ding YD. [Fly-probing-acupoint manipulation as a main treatment for lumbago] [Chinese]. Shanghai J Acupunct Moxibustion. 1998;17(5):25-6.
89 Luo S. A combined treatment of scalp acupuncture and traction in 108 cases of prolapse of the lumbar intervertebral disc. J Tradit Chin Med. Sep. 2007;27(3):178-9. [pmid: 17955652].
90 Peng Y, Y, Huang Y, et al. [Clinical study on round-sharp needle therapy combined with massage for prolapse of lumbar intervertebral disk]. Zhongguo Zhen Jiu. 2006;26(OCT):719-23. [pmid: 17117572].
91 Zhou Y, L, Liu Y, et al. [Clinical study on analgesic effect of Huaisanzhen on the nerve root pain due to prolapse of lumbar intervertebral disc]. Zhongguo Zhen Jiu. 2005;25(Jan):31-3. [pmid: 16309152].
92 Zhang Y, Chen F, Wu S. [Clinical observation on O3 acupoint injection for treatment of low back pain]. [Chinese]. Zhongguo Zhen Jiu. Feb. 2007;27(2):115-6. [pmid: 17370494].
93 Ratcliffe J, Thomas KJ, MacPherson H, et al. A randomised controlled trial of acupuncture care for persistent low back pain: cost effectiveness analysis.[see comment]. BMJ. Sep 23. 2006;333(7569):626. 2006. [pmid: 16980315].
94 Tsukayama H, Yamashita H, Amagai H, et al. Randomised controlled trial comparing the effectiveness of electroacupuncture and TENS for low back pain: a preliminary study for a pragmatic trial. Acupunct Med. Dec. 2002;20(4):175-80. [pmid: 12512791].
95 Sakai T, Tsutani K, Tsukayama H, et al. Multi-center randomized controlled trial of acupuncture with electric stimulation and acupuncture-like transcutaneous electricial nerve stimulation for lumbago. J Japan Soc Acupunct Moxibustion. 2001;51:175-84.
96 He RY. Clinical observation on treatment of lumbago due to cold-dampness by warm-acupuncture plus Chinese medicine. Chinese Acupunct Moxibustion. 1997;17(5):279-80.
97 Thomas KJ, MacPherson H, Ratcliffe J, et al. Longer term clinical and economic benefits of offering acupuncture care to patients with chronic low back pain. Health Technol Assess. 2005;9(32):1-109.
98 Wang ZX. [Clinical observation on electroacupuncture at acupoints for treatment of senile radical sciatica]. Zhongguo Zhen Jiu. Feb. 2009;29(2):126-8. [pmid: 19391537].
99 Wu YC. [Clinical observations on electroacupuncture treatment of lumbar intervertebral disc protrusion] [Chinese]. Shanghai J Acupunct Moxibustion. 2004;23(5):15-7.
100 Lee J-W, Kim D-I. A randomized controlled trial to verify effects of Kuesu Point on low back pain and accompanied sciatica. Korean J Oriental Med. 2007;28(4):86-94.
101 Garvey TA, Marks MR, Wiesel SW. A prospective, randomized, double-blind evaluation of trigger-point injection therapy for low-back pain. Spine. Sep. 1989;14(9):962-4. [pmid: 2528826].
102 Mencke M, Wieden TE, Hoppe M, et al. Acupuncture of shoulder pain and low back pain. Two prospective double-blind studies. [German]. Akupunktur. 1988;16(4):204-15.
103 Inoue M, Ktakouji H, Ikeuchi R, et al. [Randomized controlled pilot study comparing manual acupuncture with sham acupuncture for lumbago (2nd report)]. J Japan Soc Acupunct Moxibustion. 2001;51(3):412.
104 Kurosu Y. Acupuncture and moxibustion for lumbago (II) - Compartative experiment of the therapeutic effectiveness of acupuncture and garlic moxibustion. J Japan Soc Acupunct Moxibustion. 1979;28(2):31-4.
105 Edelist G, Gross AE, Langer F. Treatment of low back pain with acupuncture. Can Anaesth Soc J. 1976;23(3):303-6. [pmid: 132988].
106 Kawase Y, Ishigami T, Nakamura H, et al. Acupuncture treatment for lower back pain: Multi-center randomized controlled trial using sham acupuncture as a control. J Japan Soc Acupunct Moxibustion. 2006;(56):140-9.
107 UK BEAM Trial Team. United Kingdom back pain exercise and manipulation (UK BEAM) randomised trial: effectiveness of physical treatments for back pain in primary care. [see comment]. BMJ. Dec 11. 2004;329(7479):1377. 2004. [pmid: 15556955].
108 Hoiriis KT, Pfleger B, McDuffie FC, et al. A randomized clinical trial comparing chiropractic adjustments to muscle relaxants for subacute low back pain. J Manipulative Physiol Ther. Jul. 2004;27(6):388-98. [pmid: 15319761].
109 Hsieh CY, Adams AH, Tobis J, et al. Effectiveness of four conservative treatments for subacute low back pain: a randomized clinical trial. Spine. Jun 1. 2002;27(11):1142-8. [pmid: 12045509].
110 Seferlis T, Lindholm L, Nemeth G. Cost-minimisation analysis of three conservative treatment programmes in 180 patients sick-listed for acute low-back pain. Scand J Prim Health Care. Mar. 2000;18(1):53-7. [pmid: 10811045].
111 Pope MH, Phillips RB, Haugh LD, et al. A prospective randomized three-week trial of spinal manipulation, transcutaneous muscle stimulation, massage and corset in the treatment of subacute low back pain. Spine. Nov 15. 1994;19(22):2571-7. [pmid: 7855683].
112 Sanders GE, Reinert O, Tepe R, et al. Chiropractic adjustive manipulation on subjects with acute low back pain: visual analog pain scores and plasma beta-endorphin levels. J Manipulative Physiol Ther. Sep. 1990;13(7):391-5. [pmid: 2145384].
113 Hadler NM, Curtis P, Gillings DB, et al. A benefit of spinal manipulation as adjunctive therapy for acute low-back pain: a stratified controlled trial. Spine. Sep. 1987;12(7):703-6.
114 Alaksiev A, Kraev T. Postisometric relaxation versus high velocity low amplitude techniques in low back pain. Manuelle Medizin. Feb. 1996;34(1):14-7.
115 Rasmussen GG. Manipulation in treatment of low back pain (a randomized clinical trial. Manual Med. 1979;17(1):8-10.
116 Shah M. Study to evaluate outcome of acute backache with drug therapy and manipulation. Manual Med. 1989;4(3):99.
117 Morton JE. Manipulation in the treatment of acute low back pain. J Man Manip Ther. 1999;7(4):182-9.
118 Hoehler FK, Tobis JS, Buerger AA. Spinal manipulation for low back pain. JAMA. May 8. 1981;245(18):1835-8. [pmid: 6453240].
119 Postacchini F, Facchini M, Palieri P. Efficacy of various forms of conservative treatment in low back pain. Neuro-Orthopedics. 1988;(6):28-35.
120 Haas M, Groupp E, Kraemer DF. Dose-response for chiropractic care of chronic low back pain. Spine J. Sep. 2004;4(5):574-83. [pmid: 15363431].
121 Niemisto L, Lahtinen-Suopanki T, Rissanen P, et al. A randomized trial of combined manipulation, stabilizing exercises, and physician consultation compared to physician consultation alone for chronic low back pain. Spine. Oct 1. 2003;28(19):2185-91. [pmid: 14520029].
122 Triano JJ, McGregor M, Hondras MA, et al. Manipulative therapy versus education programs in chronic low back pain. Spine. Apr 15. 1995;20(8):948-55. [pmid: 7644961].
123 Cote P, Mior SA, Vernon H. The short-term effect of a spinal manipulation on pain/pressure threshold in patients with chronic mechanical low back pain. J Manipulative Physiol Ther. Jul. 1994;17(6):364-8. [pmid: 7964196].
124 Mohseni-Bandpei MA, Critchley J, Staunton T, et al. A prospective randomised controlled trial of spinal manipulation and ultrasound in the treatment of chronic low back pain. Physiotherapy. 2006;92(1):34-42.
125 Buerger AA. A controlled trial of rotational manipulation in low back pain. Manuelle Medizin. 1980;18(2):17-26.
126 Waagen GN, Haldeman S, Cook G, et al. Short term trial of chiropractic adjustments for the relief of chronic low back pain. Manual Med. 1986;2:63-7.
127 Rasmussen J, Laetgaard J, Lindecrona AL, et al. Manipulation does not add to the effect of extension exercises in chronic low-back pain (LBP). A randomized, controlled, double blind study. Joint Bone Spine. Dec. 2008;75(6):708-13. [pmid: 19028434].
128 Lalanne K, Lafond D, Descarreaux M. Modulation of the flexion-relaxation response by spinal manipulative therapy: a control group study. J Manipulative Physiol Ther. Mar. 2009;32(3):203-9. [pmid: 19362230].
129 Giles LG, Muller R. Chronic spinal pain syndromes: a clinical pilot trial comparing acupuncture, a nonsteroidal anti-inflammatory drug, and spinal manipulation. [see comment]. J Manipulative Physiol Ther. Jul. 1999;22(6):376-81. [pmid: 10478769].
130 Herzog W, Conway PJ, Willcox BJ. Effects of different treatment modalities on gait symmetry and clinical measures for sacroiliac joint patients. J Manipulative Physiol Ther. Feb. 1991;14(2):104-9. [pmid: 1826920].
131 Jull GA, Stanton WR. Predictors of responsiveness to physiotherapy management of cervicogenic headache. Cephalalgia. Feb. 2005;25(2):101-8. [pmid: 15658946].
132 Mathews W, Morkel M, Mathews J. Manipulation and traction for lumbago and sciatica: Physiotherapeutic techniques used in two controlled trials. Physiother Pract. 1988;4(4):201-6.
133 Zhang WB, Cao Y, Sun YA, et al. [Manipulative reduction for lumbar intervertebral disc herniation: a controlled clinical trial]. [Chinese]. Zhongguo Gushang. Apr. 2008;21(4):273-5. [pmid: 19102187].
134 Childs JD, Fritz JM, Flynn TW, et al. A clinical prediction rule to identify patients with low back pain most likely to benefit from spinal manipulation: a validation study.[see comment][summary for patients in Ann Intern Med. 2004 Dec 21;141(12):I39; PMID: 15611484]. Ann Intern Med. Dec 21. 2004;141(12):920-8. [pmid: 15611489].
135 UK BEAM Trial Team. United Kingdom back pain exercise and manipulation (UK BEAM) randomised trial: cost effectiveness of physical treatments for back pain in primary care. [see comment]. BMJ. Dec 11. 2004;329(7479):1381. 2004. [pmid: 15556954].
136 Cherkin DC, Deyo RA, Battie M, et al. A comparison of physical therapy, chiropractic manipulation, and provision of an educational booklet for the treatment of patients with low back pain. [see comment]. N Eng J Med. Oct 8. 1998;339(15):1021-9.
137 Hoehler FK, Tobis JS, Buerger AA. Spinal manipulation for low back pain. JAMA. May 8. 1981;245(18):1835-8. [pmid: 6453240].
138 Bronfort G. Chiropractic versus general medical treatment of low back pain: a small scale controlled clinical trial. Am J Chiropractic Med. Dec. 1989;2(4):145-50.
139 Rupert RL, Thompson P, Wagon R. Chiropractic adjustments: Results of a controlled clinical trial in Egypt. ICA Rev. May. 1985;41(3):58-60.
140 Hoiriis K. A clinical trial comparing upper cervical and full spine chiropractic care for chronic low back pain. J Chiropr Educ. 1999;13(1):67-8.
141 Evans DP, Burke MS, Lloyd KN, et al. Lumbar spinal manipulation on trial. Part I--clinical assessment. Rheumatol Rehabil. Feb. 1978;17(1):46-53. [pmid: 153574].
142 Hondras MA, Long CR, Cao Y, et al. A randomized controlled trial comparing 2 types of spinal manipulation and minimal conservative medical care for adults 55 years and older with subacute or chronic low back pain. Journal of Manipulative & Physiological Therapeutics. Jun. 2009;32(5):330-43. [pmid: 19539115].
143 Dai D, Fang M, Shen G. A study on lumbar stability of degenerative spondylolisthesis treated with spine fine adjusting manipulation. [Chinese]. Chinese J of Rehab Med. 2006;21(12):1110-2.
144 Shearar K, A, Colloca C, et al. A randomized clinical trial of the relative effectiveness of manual versus mechanical force chiropractic adjustments in the management of sacroiliac joint syndrome. J Chiropr Edu. 2004;18(SPR):29.
145 Hanrahan S, Van Lunen BL, Tamburello M, et al. The short-term effects of joint mobilizations on acute mechanical low back dysfunction in collegiate athletes. J Athl Training. 2005;40(2):88-93.
146 Aleksiev A. Longitudinal comparative study on the outcome of inpatient treatment of low back pain with manual therapy vs. Physical therapy. J Orthopaedic Med. 1995;17(1):10-4.
147 Wreje U, Nordgren B, Aberg H. Treatment of pelvic joint dysfunction in primary care--a controlled study. [erratum appears in Scand J Prim Health Care 1993 Mar;11(1):25]. Scand J Prim Health Care. Dec. 1992;10(4):310-5. [pmid: 1480873].
148 Timm KE. A randomized-control study of active and passive treatments for chronic low back pain following L5 laminectomy. The Journal of orthopaedic and sports physical therapy. 1994;20(6):276-86. [pmid: 7849747].
149 Ritvanen T, Zaproudina N, Nissen M, et al. Dynamic surface electromyographic responses in chronic low back pain treated by traditional bone setting and conventional physical therapy. [erratum appears in J Manipulative Physiol Ther. 2007 Jul-Aug;30(6):472]. J Manipulative Physiol Ther. Jan. 2007;30(1):31-7. [pmid: 17224353].
150 Hemmila HM, Keinanen-Kiukaanniemi SM, Levoska S, et al. Long-term effectiveness of bone-setting, light exercise therapy, and physiotherapy for prolonged back pain: a randomized controlled trial. J Manipulative Physiol Ther. Feb. 2002;25(2):99-104. [pmid: 11896377].
151 Mackawan S, Eungpinichpong W, Pantumethakul R, et al. Effects of traditional Thai massage versus joint mobilization on substance P and pain perception in patients with non-specific low back pain. J Bodywork Movement Ther. 2007;11(1):9-16.
152 Lopez de Celis C, Barra Lopez ME, Villar ME, et al. Effectiveness of the posteroanterior mobilization in the lumbar raquis with the Kaltenborn wedge in chronic low back pain patients [Spanish]. Fisioterapia. Nov-Dec. 2007;29(6):261-9. (30 ref) 2007;(6):261-9.
153 Hemmila HM, Keinanen-Kiukaanniemi SM, Levoska S, et al. Does folk medicine work? A randomized clinical trial on patients with prolonged back pain. Arch Phys Med Rehabil. Jun. 1997;78(6):571-7. [pmid: 9196462].
154 Konstantinou K, Foster N, Rushton A, et al. Flexion mobilizations with movement techniques: the immediate effects on range of movement and pain in subjects with low back pain. J Manipulative Physiol Ther. Mar. 2007;30(3):178-85. [pmid: 17416271].
155 Hoving JL, de Vet HC, Koes BW, et al. Manual therapy, physical therapy, or continued care by the general practitioner for patients with neck pain: long-term results from a pragmatic randomized clinical trial. Clin J Pain. May. 2006;22(4):370-7. [pmid: 16691091].
156 Chiradejnant A, Maher CG, Latimer J, et al. Efficacy of “therapist-selected” versus “randomly selected” mobilisation techniques for the treatment of low back pain: a randomised controlled trial. Aust J Physiother. 2003;49(4):233-41. [pmid: 14632622].
157 Goodsell M, Lee M, Latimer J. Short-term effects of lumbar posteroanterior mobilization in individuals with low-back pain. J Manipulative Physiol Ther. Jun. 2000;23(5):332-42. [pmid: 10863253].
158 Chiradejnant A, Latimer J, Maher CG, et al. Does the choice of spinal level treated during posteroanterior (PA) mobilisation affect treatment outcome?. Physiotherapy Theory and Practice. Dec. 2002;18(4):165-74.
159 Powers CM, Beneck GJ, Kulig K, et al. Effects of a single session of posterior-to-anterior spinal mobilization and press-up exercise on pain response and lumbar spine extension in people with nonspecific low back pain. Physical Therapy. 2008;88(4):485-93. [pmid: 18258767].
160 Hancock MJ, Maher CG, Latimer J, et al. Assessment of diclofenac or spinal manipulative therapy, or both, in addition to recommended first-line treatment for acute low back pain: a randomised controlled trial. [see comment]. Lancet. Nov 10. 2007;370(9599):1638-43. [pmid: 17993364].
161 Hurley DA, McDonough SM, Dempster M, et al. A randomized clinical trial of manipulative therapy and interferential therapy for acute low back pain. Spine. Oct 15. 2004;29(20):2207-16. [pmid: 15480130].
162 Aure OF, Nilsen JH, Vasseljen O. Manual therapy and exercise therapy in patients with chronic low back pain: a randomized, controlled trial with 1-year follow-up. [see comment]. Spine. Mar 15. 2003;28(6):525-31. [pmid: 12642755].
163 Ferreira ML, Ferreira PH, Latimer J, et al. Comparison of general exercise, motor control exercise and spinal manipulative therapy for chronic low back pain: A randomized trial. Pain. Sep. 2007;131(1-2):31-7. [pmid: 17250965].
164 Hurwitz EL, Morgenstern H, Kominski GF, et al. A randomized trial of chiropractic and medical care for patients with low back pain: eighteen-month follow-up outcomes from the UCLA low back pain study. Spine. Mar 15. 2006;31(6):611-21. [pmid: 16540862].
165 Koes BW, Bouter LM, van MH, et al. A blinded randomized clinical trial of manual therapy and physiotherapy for chronic back and neck complaints: physical outcome measures. [see comment]. J Manipulative Physiol Ther. Jan. 1992;15(1):16-23. [pmid: 1531487].
166 MacDonald RS, Bell CMJ. An open controlled assessment of osteopathic manipulation in nonspecific low-back pain. Spine. 1990;15(5):364-70. [pmid: 2141951].
167 Meade TW, Dyer S, Browne W, et al. Low back pain of mechanical origin: randomized comparison of chiropractic and hospital outpatient treatment. J Orthop Sports Phys Ther. 1991;13(6):278-87. [pmid: 18784399].
168 Meade TW, Dyer S, Browne W, et al. Randomised comparison of chiropractic and hospital outpatient management for low back pain: results from extended follow up. [see comment]. BMJ. Aug 5. 1995;311(7001):349-51. [pmid: 7640538].
169 Meade TW, Dyer S, Browne W, et al. Low back pain of mechanical origin: randomised comparison of chiropractic and hospital outpatient treatment. [see comment]. BMJ. Jun 2. 1990;300(6737):1431-7. [pmid: 2143092].
170 Meade TW, Dyer S, Browne W, et al. Low back pain of mechanical origin: randomized comparison of chiropractic and hospital outpatient treatment. Er J Chiropract. Sep. 1990;38(3):92-107.
171 Sims-Williams H, Jayson MI, Young SM, et al. Controlled trial of mobilisation and manipulation for low back pain: hospital patients. BMJ. Nov 24. 1979;2(6201):1318-20. [pmid: 160266].
172 Kominski GF, Heslin KC, Morgenstern H, et al. Economic evaluation of four treatments for low-back pain: results from a randomized controlled trial. [see comment]. Med Care. May. 2005;43(5):428-35. [pmid: 15838406].
173 Cambron JA, Gudavalli MR, Hedeker D, et al. One-year follow-up of a randomized clinical trial comparing flexion distraction with an exercise program for chronic low-back pain. J Altern Complement Med. Sep. 2006;12(7):659-68. [pmid: 16970536].
174 Hawk C, Long CR, Rowell RM, et al. A randomized trial investigating a chiropractic manual placebo: a novel design using standardized forces in the delivery of active and control treatments. J Altern Complement Med. Feb. 2005;11(1):109-17. [pmid: 15750369].
175 Hawk C, Azad A, Phongphua C, et al. Preliminary study of the effects of a placebo chiropractic treatment with sham adjustments. [see comment]. J Manipulative Physiol Ther. Sep. 1999;22(7):436-43. [pmid: 10519559].
176 Beyerman KL, Palmerino MB, Zohn LE, et al. Efficacy of treating low back pain and dysfunction secondary to osteoarthritis: chiropractic care compared with moist heat alone. J Manipulative Physiol Ther. Feb. 2006;29(2):107-14. [pmid: 16461169].
177 Preyde M. Effectiveness of massage therapy for subacute low-back pain: a randomized controlled trial. Can Med Assoc J. Jun 27. 2000;162(13):1815-20. [pmid: 10906914].
178 Konrad K, Tatrai T, Hunka A, et al. Controlled trial of balneotherapy in treatment of low back pain. Ann Rhuem Dis. Jun. 1992;51(6):820-2.
179 Farasyn A, Meeusen R, Nijs J. A pilot randomized placebo-controlled trial of roptrotherapy in patients with subacute non-specific low back pain. J Back Musculoskeletal Rehabil. 2006;19(4):111-7.
180 Yip YB, Tse SH. The effectiveness of relaxation acupoint stimulation and acupressure with aromatic lavender essential oil for non-specific low back pain in Hong Kong: a randomised controlled trial. Complement Ther Med. Mar. 2004;12(1):28-37. [pmid: 15130569].
181 Little P, Lewith G, Webley F, et al. Randomised controlled trial of Alexander technique lessons, exercise, and massage (ATEAM) for chronic and recurrent back pain. BMJ. 2008;337:a884. 2008.:a884, 2008. [pmid: 18713809].
182 Little P, Lewith G, Webley F, et al. Randomised controlled trial of Alexander technique lessons, exercise, and massage (ATEAM) for chronic and recurrent back pain. British Journal of Sports Medicine. Dec. 2008;42(12):965-8. [pmid: 19096019].
183 Hollinghurst S, Sharp D, Ballard K, et al. Randomised controlled trial of Alexander technique lessons, exercise, and massage (ATEAM) for chronic and recurrent back pain: economic evaluation. BMJ. 2008;337:a2656. [pmid: 19074232].
184 Zaproudina N, Hietikko T, Hanninen OO, et al. Effectiveness of traditional bone setting in treating chronic low back pain: a randomised pilot trial. Complement Ther Med. Jan. 2009;17(1):23-8. [pmid: 19114225].
185 Quinn F, Hughes CM, Baxter GD. Reflexology in the management of low back pain: a pilot randomised controlled trial. Complement Ther Med. Feb. 2008;16(1):3-8. [pmid: 18346622].
186 Poole H, Glenn S, Murphy P. A randomised controlled study of reflexology for the management of chronic low back pain. European Journal of Pain. Nov. 2007;11(8):878-87. [pmid: 17459741].
187 Hsieh LL, Kuo CH, Lee LH, et al. Treatment of low back pain by acupressure and physical therapy: randomised controlled trial. [see comment]. BMJ. Mar 25. 2006;332(7543):696-700. [pmid: 16488895].
188 Geisser ME, Wiggert EA, Haig AJ, et al. A randomized, controlled trial of manual therapy and specific adjuvant exercise for chronic low back pain. Clin J Pain. Nov. 2005;21(6):463-70. [pmid: 16215330].
189 Hsieh LL, Kuo CH, Yen MF, et al. A randomized controlled clinical trial for low back pain treated by acupressure and physical therapy. Prev Med. Jul. 2004;39(1):168-76. [pmid: 15207999].
190 Hernandez-Reif M, Field T, Krasnegor J, et al. Lower back pain is reduced and range of motion increased after massage therapy. Int J Neurosci. 2001;106(3-4):131-45. [pmid: 11264915].
191 Field T, Hernandez-Reif M, Diego M, et al. Lower back pain and sleep disturbance are reduced following massage therapy. J Bodywork Movement Ther. 2007;11(2):141-5.
192 Franke A, Gebauer S, Franke K, et al. [Acupuncture massage vs Swedish massage and individual exercise vs group exercise in low back pain sufferers--a randomized controlled clinical trial in a 2 x 2 factorial design]. [German]. Forsch Komplementarmed Klass Naturheilkd. Dec. 2000;7(6):286-93. [pmid: 11155022].
193 Zhang J-F, Chen W-H. Curative effect of nonoperative therapy for the lumbar disc herniation. [Chinese]. Chinese J Clin Rehab. 2004;8(11):2006-7.
194 Chatchawan U, Thinkhamrop B, Kharmwan S, et al. Effectiveness of traditional Thai massage versus Swedish massage among patients with back pain associated with myofascial trigger points. J Bodywork Movement Ther. 2005;9(4):298-309.
195 Li Z-Y, Chen P-Q, Gong L, et al. Analgesic effect on lumbar intervertebral disc protrusion-induced back-leg pain by kneading method of taking the tender point as acupoint. [Chinese]. Chinese J Clin Rehab. 2006;10(23):25-7.
196 Aigner N, Fialka C, Stocker R, et al. Acupuncture versus laser acupuncture in the treatment of whiplash injury - A prospective randomized study. [German]. Dtsch Z Akupunkt. 1999;42(1):4-12.
197 Venancio RA, Alencar FG, Zamperini C. Different substances and dry-needling injections in patients with myofascial pain and headaches. Cranio. Apr. 2008;26(2):96-103. [pmid: 18468269].
198 Venancio RA, Alencar FG Jr., Zamperini C. Botulinum toxin, lidocaine, and dry-needling injections in patients with myofascial pain and headaches. Cranio. Jan. 2009;27(1):46-53. [pmid: 19241799].
199 Ga H, Choi JH, Park CH, et al. Acupuncture needling versus lidocaine injection of trigger points in myofascial pain syndrome in elderly patients--a randomised trial. Acupunct Med. Dec. 2007;25(4):130-6. [pmid: 18160923].
200 Ga H, Choi JH, Park CH, et al. Dry needling of trigger points with and without paraspinal needling in myofascial pain syndromes in elderly patients. J Altern Complement Med. Jul. 2007;13(6):617-24. [pmid: 17718644].
201 Lu YX, Shan QH. [Clinical observation on treatment of cervicogenic headache with turtle-probing needling at Tianzhu (BL 10)]. [Chinese]. Zhongguo Zhen Jiu. Nov. 2006;26(11):796-8. [pmid: 17165503].
202 Irnich D, Behrens N, Gleditsch JM, et al. Immediate effects of dry needling and acupuncture at distant points in chronic neck pain: results of a randomized, double-blind, sham-controlled crossover trial. Pain. Sep. 2002;99(1-2):83-9. [pmid: 12237186].
203 Irnich D, Behrens N, ea. Abstract of Immediate effects of dry needling and acupuncture at distant points in chronic neck pain: results of a randomized, double-blind, sham- controlled crossover trial. Complement Ther Med. 2002;10(2):109.
204 Zhu XM, Polus B. A controlled trial on acupuncture for chronic neck pain. Am J Chinese Med. 2002;30(1):13-28.
205 Irnich D, Behrens N, Molzen H, et al. Randomised trial of acupuncture compared with conventional massage and “sham” laser acupuncture for treatment of chronic neck pain. [see comment]. BMJ. Jun 30. 2001;322(7302):1574-8. [pmid: 11431299].
206 Irnich D. Randomised, placebo, controlled, multicentre trial of acupuncture for the treatment of chronic neck pain. Dtsch Z Akupunkt. 2000;43(1):40.
207 Konig A, Radke S, Molzen H, et al. [Randomised trial of acupuncture compared with conventional massage and “sham” laser acupuncture for treatment of chronic neck pain - range of motion analysis]. [German]. Z Orthop Ihre Grenzgeb. Jul. 2003;141(4):395-400. [pmid: 12928995].
208 White PF, Craig WF, Vakharia AS, et al. Percutaneous neuromodulation therapy: Does the location of electrical stimulation effect the acute analgesic response?. Anesth Analg. 2000;91(4):949-54. [pmid: 11004055].
209 Lundeberg T, Eriksson SV, Lundeberg S, et al. Effect of acupuncture and naloxone in patients with osteoarthritis pain. A sham acupuncture controlled study. Pain Clinic. 1991;4(3):155-61.
210 Ceccherelli F, Tortora P, Nassimbeni C, et al. The therapeutic efficacy of somatic acupuncture is not increased by auriculotherapy: a randomised, blind control study in cervical myofascial pain. Complement Ther Med. Mar. 2006;14(1):47-52. [pmid: 16473753].
211 Thomas M, Eriksson SV, Lundeberg T. A comparative study of diazepam and acupuncture in patients with osteoarthritis pain: a placebo controlled study. Am J Chinese Med. 1991;19(2):95-100.
212 Zhao ZY, Cai D, Liang F. [Observation on therapeutic effect of Shencongding moxibustion on cervical headache] [Chinese]. Chinese Acupunct Moxibustion. 2004;24(6):389-91.
213 Yang T, Sun F, Zhou YL. [Clinical observation on acupoint sticking therapy for treatment of chronic pain of cervical intervertebral disc]. Zhongguo Zhen Jiu. Mar. 2009;29(3):197-9. [pmid: 19358501].
214 Abernethy AP. Randomized controlled trial of acupuncture for chronic neck pain. J Pain Palliat Care Pharmacother. 2008;(2):145-6. [pmid: 19042839].
215 Itoh K, Katsumi Y, Hirota S, et al. Randomised trial of trigger point acupuncture compared with other acupuncture for treatment of chronic neck pain. Complement Ther Med. Sep. 2007;15(3):172-9. [pmid: 17709062].
216 Salter GC, Roman M, Bland MJ, et al. Acupuncture for chronic neck pain: a pilot for a randomised controlled trial. BMC Musculoskelet Disord. 2006;7:99. [pmid: 17156464].
217 Seidel U, Uhlemann C. A randomised controlled double-blind trial comparing dosed lasertherapy on acupuncture points and acupuncture for chronic cervical syndrome. [German]. Dtsch Z Akupunkt. 2002;45(4):258-69.
218 Seidel U. Acupuncture versus laser acupuncture for neck pain. Focus Altern Complement Ther. 2003;8(3):259-30.
219 Petrie JP, Hazleman BL. A controlled study of acupuncture in neck pain. Br J Rheumatol. Aug. 1986;25(3):271-5. [pmid: 3524727].
220 Petrie JP, Langley GB. Acupuncture in the treatment of chronic cervical pain. A pilot study. Clin Exp Rheumatol. Oct. 1983;1(4):333-6. [pmid: 6335859].
221 Gallacchi G, Muller W. [Acupuncture--does it contribute anything?]. [German]. Schweiz Rundsch Med Prax. May 31. 1983;72(22):778-82. [pmid: 6224144].
222 Gallacchi G, Muller W, Plattner GR, et al. [Acupuncture and laser treatment in cervical and lumbar syndrome]. [German]. Schweiz Med Wochenschr. Sep 12. 1981;111(37):1360-6. [pmid: 6457384].
223 Coan RM, Wong G, Coan PL. The acupuncture treatment of neck pain: a randomized controlled study. Am J Chinese Med. 1981;9(4):326-32.
224 David J, Modi S, Aluko AA, et al. Chronic neck pain: a comparison of acupuncture treatment and physiotherapy. Br J Rheumatol. Oct. 1998;37(10):1118-22. [pmid: 9825752].
225 Vas J, Perea-Milla E, Mendez C, et al. Efficacy and safety of acupuncture for chronic uncomplicated neck pain: a randomised controlled study. Pain. Dec 15. 2006;126(1-3):245-55. [pmid: 16934402].
226 White P, Lewith G, Prescott P, et al. Acupuncture versus placebo for the treatment of chronic mechanical neck pain: a randomized, controlled trial.[see comment][summary for patients in Ann Intern Med. 2004 Dec 21;141(12):I26; PMID: 15611483]. Ann Intern Med. Dec 21. 2004;141(12):911-9. [pmid: 15611488].
227 White PJ. Abstract of The efficacy of acupuncture for the treatment of chronic mechanical neck pain - a randomised, controlled, single blind trial. Complement Ther Med. 2002;10(2):113.
228 Sator-Katzenschlager SM, Szeles JC, Scharbert G, et al. Electrical stimulation of auricular acupuncture points is more effective than conventional manual auricular acupuncture in chronic cervical pain: a pilot study. Anesth Analg. Nov. 2003;97(5):1469-73. [pmid: 14570667].
229 Nabeta T, Kawakita K. Relief of chronic neck and shoulder pain by manual acupuncture to tender points--a sham-controlled randomized trial. Complement Ther Med. Dec. 2002;10(4):217-22. [pmid: 12594972].
230 Bin X, Ling F, Lingxiang H. Clinical observation on cervical spondylopathy of the vertebroarterial type treated by electro-acupuncture. J Tradit Chin Med. 2007;27(1):39-42. [pmid: 17393625].
231 Shang X, Meng X, Dong H, et al. [Clinical observations on the treatment of nerve-root cervical spondylopathy by the combination of adjacent and remote acupoints] [Chinese]. Shanghai J Acupunct Moxibustion. 2002;21(6):12-3.
232 Li XH. [Therapeutic effect of centro-square needling Dazhui (GV 14) on cervical spondylosis] [Chinese]. Chinese Acupunct Moxibustion. 2004;24(7):455-6.
233 Zhuang L-X, Zhu F-P. Effect of pressed acupuncture at baihui acupoint on thromboxane A^2^ and prostacyclin in treating vertebral artery type of cervical spondylosis. [Chinese]. Chinese J Clin Rehab. 2004;8(30):6672-3.
234 Lin M-N, Liu X-X, Liu J-H, et al. Needle scalpel combined with massage therapy and simple massage therapy for nerve-root type cervical spondylopathy: A randomized controlled analysis on 100 patients. Chinese J Clin Rehab. 2004;8(23):4920-1.
235 Chu J. Does EMG (dry needling) reduce myofascial pain symptoms due to cervical nerve root irritation?. Electroencephalogr Clin Neurophysiol. Aug. 1997;37(5):259-72.
236 Zhu HZ, Quan WC, Zhang XF, et al. [Evaluation on clinical therapeutic effect of needle-knife therapy on cervical spondylosis]. [Chinese]. Zhongguo Zhen Jiu. May. 2006;26(5):316-8. [pmid: 16739840].
237 Jia CS, Shi J, Ma XS, et al. [Comparison of the analgesic effect of acupuncture between otopoint-penetrative needling and otopoint-straight needling for cervical type and nerve-root type cervicospondylopathy]. [Chinese]. Chen Tzu Yen Chiu. 2007;32(3):186-9. [pmid: 17691577].
238 Huang YF, Wang TF, Liu Y, et al. [Clinical observation on Jiquan (HT 1) for treatment of cervical spondylosis of nerve root type]. [Chinese]. Zhongguo Zhen Jiu. Jun. 2008;28(6):427-8. [pmid: 18630541].
239 Wang XL. [Observation on therapeutic effect of shu-needling therapy as main on cervical spondylosis of nerve root type]. [Chinese]. Zhongguo Zhen Jiu. Jul. 2008;28(7):497-8. [pmid: 18678161].
240 Zhang W, Zheng J, Zhao X. Treatment of arterial-type cervical spondylosis with acupoint-injection, combined with massage manipulation. Int J Clin Acupunct. 2005;14(4):261-5.
241 Fu ZH, Wang JH, Sun JH, et al. Fu's subcutaneous needling: possible clinical evidence of the subcutaneous connective tissue in acupuncture. J Altern Complement Med. Jan. 2007;13(1):47-51. [pmid: 17309377].
242 Liang ZH, Yang YH, Yu P, et al. [Logistic regression analysis on therapeutic effect of acupuncture on neck pain caused by cervical spondylosis and factors influencing therapeutic effect]. Zhongguo Zhen Jiu. Mar. 2009;29(3):173-6. [pmid: 19358495].
243 Zeng L. [Treatment of cervical spondylopathy by point-through-point Acupuncture] [Chinese]. Shanghai J Acupunct Moxibustion. 2005;24(7):9-10.
244 Wang XL, Huang HY. [Observation on therapeutic effect of long-time needle retention at Baihui (GV 20) on vertebroarterial cervical spondylopathy]. [Chinese]. Zhongguo Zhen Jiu. Jun. 2007;27(6):415-6. [pmid: 17663103].
245 Fu WB, Zhang HL, Fan L. [Treatment of cervical spondylopathy by needle pricking: A clinical observation of 56 cases] [Chinese]. New J Tradit Chinese Med. 2005;37(4):65-6.
246 Edwards J, Knowles N. Superficial dry needling and active stretching in the treatment of myofascial pain--a randomised controlled trial. Acupunct Med. Sep. 2003;21(3):80-6. [pmid: 14620302].
247 Wang C, Xiong Z, Deng C, et al. Miniscalpel-needle versus triggerpoint injection for cervical myofascial pain syndrome: a randomized comparative trial. [see comment]. J Altern Complement Med. Jan. 2007;13(1):14-6. [pmid: 17309371].
248 Buchmann J, Wende K, Kundt G, et al. Manual treatment effects to the upper cervical apophysial joints before, during, and after endotracheal anesthesia: A placebo-controlled comparison. Am J Phys Med Rehabil. 2005;84(4):251-7. [pmid: 15785257].
249 Pikula JR. The effect of spinal manipulative therapy (SMT) on pain reduction and range of motion in patients with acute unilateral neck pain: a pilot study. J Can Chiropract Assoc. Jun. 1999;43(2):111-9.
250 Yurkiw D, Mior S. Comparison of two chiropractic techniques on pain and lateral flexion in neck pain patients: a pilot study. Chiropractic Technique. Nov. 1996;8(4):155-62. (25 ref) 1996;(4):155-62.
251 Gonzalez-Iglesias J, Fernandez-de-Las-Penas C, Cleland JA, et al. Thoracic spine manipulation for the management of patients with neck pain: a randomized clinical trial. J Orthop Sports Phys Ther. Jan. 2009;39(1):20-7. [pmid: 19209478].
252 Muller R, Giles LG. Long-term follow-up of a randomized clinical trial assessing the efficacy of medication, acupuncture, and spinal manipulation for chronic mechanical spinal pain syndromes. J Manipulative Physiol Ther. Jan. 2005;28(1):3-11. [pmid: 15726029].
253 Sloop PR, Smith DS, Goldenberg E, et al. Manipulation for chronic neck pain. A double-blind controlled study. Spine. Nov. 1982;7(6):532-5. [pmid: 6762670].
254 Cleland JA, Childs JD, McRae M, et al. Immediate effects of thoracic manipulation in patients with neck pain: a randomized clinical trial. [see comment]. Manual Therapy. May. 2005;10(2):127-35. [pmid: 15922233].
255 Bischoff A, Nurnberger A, Voigt P, et al. Osteopathy alleviates pain in chronic non-specific neck pain: randomized controlled trial. Focus Altern Complement Ther. DEC. 2003;8(4):537.
256 Chen L, Zhang X-L, Ding H, et al. Comparative study on effects of manipulation treatment and transcutaneous electrical nerve stimulation on patients with cervicogenic headache. [Chinese]. Journal of Chinese Integrative Medicine. 2007;5(4):403-6. [pmid: 17631795].
257 Haas M, Groupp E, Aickin M, et al. Dose response for chiropractic care of chronic cervicogenic headache and associated neck pain: a randomized pilot study. J Manipulative Physiol Ther. Nov. 2004;27(9):547-53. [pmid: 15614241].
258 Boline PD, Kassak K, Bronfort G, et al. Spinal manipulation vs. amitriptyline for the treatment of chronic tension-type headaches: A randomized clinical trial. J Manipulative Physiol Ther. 1995;18(3):148-54. [pmid: 7790794].
259 Ouseley BR, Parkin-Smith GF. Possible effects of chiropractic spinal manipulation and mobilization in the treatment of chronic tension-type headache: a pilot study. Eur J Chiropr. 2002;50(1):3-13.
260 Nilsson N, Christensen HW, Hartvigsen J. The effect of spinal manipulation in the treatment of cervicogenic headache. J Manipulative Physiol Ther. Jun. 1997;20(5):326-30. [pmid: 9200048].
261 Whittingham W, Nilsson N. Active range of motion in the cervical spine increases after spinal manipulation (toggle recoil). J Manipulative Physiol Ther. Nov. 2001;24(9):552-5. [pmid: 11753327].
262 Sterling M, Jull G, Wright A. Cervical mobilisation: concurrent effects on pain, sympathetic nervous system activity and motor activity. Man Ther. May. 2001;6(2):72-81. [pmid: 11414776].
263 Fernandez-de-Las-Penas C, Fernandez-Carnero J, Fernandez AP, et al. Dorsal manipulation in whiplash injury treatment: A randomized controlled trial. J Whiplash Relat Disord. 2004;3(2):55-72.
264 Coppieters MW, Stappaerts KH, Wouters LL, et al. Aberrant protective force generation during neural provocation testing and the effect of treatment in patients with neurogenic cervicobrachial pain. J Manipulative Physiol Ther. 2003;26(2):99-106. [pmid: 12584508].
265 Hurwitz EL, Morgenstern H, Harber P, et al. A randomized trial of chiropractic manipulation and mobilization for patients with neck pain: clinical outcomes from the UCLA neck-pain study. [see comment]. Am J Public Health. Oct. 2002;92(10):1634-41. [pmid: 12356613].
266 Cassidy JD, Lopes AA, Yong-Hing K. The immediate effect of manipulation versus mobilization on pain and range of motion in the cervical spine: a randomized controlled trial. [see comment]. J Manipulative Physiol Ther. Nov. 1992;15(9):570-5. [pmid: 1469341].
267 Martinez-Segura R, Fernandez-de-Las-Penas C, Ruiz-Saez M, et al. Immediate effects on neck pain and active range of motion after a single cervical high-velocity low-amplitude manipulation in subjects presenting with mechanical neck pain: a randomized controlled trial. J Manipulative Physiol Ther. Sep. 2006;29(7):511-7. [pmid: 16949939].
268 Haas M, Groupp E, Panzer D, et al. Efficacy of cervical endplay assessment as an indicator for spinal manipulation. [see comment]. Spine. Jun 1. 2003;28(11):1091-6. [pmid: 12782973].
269 Vernon HT, Aker P, Burns S, et al. Pressure pain threshold evaluation of the effect of spinal manipulation in the treatment of chronic neck pain: a pilot study. J Manipulative Physiol Ther. Jan. 1990;13(1):13-6. [pmid: 2324655].
270 Cleland JA, Glynn P, Whitman JM, et al. Short-term effects of thrust versus nonthrust mobilization/manipulation directed at the thoracic spine in patients with neck pain: a randomized clinical trial. Physical Therapy. Apr. 2007;87(4):431-40. [pmid: 17341509].
271 Strunk RG, Hondras MA. A feasibility study assessing manual therapies to different regions of the spine for patients with subacute or chronic neck pain. J Chiropractic Med. Mar. 2008;7(1):1-8.
272 Kanlayanaphotporn R, Chiradejnant A, Vachalathiti R. The immediate effects of mobilization technique on pain and range of motion in patients presenting with unilateral neck pain: a randomized controlled trial. Arch Phys Med Rehab. Feb. 2009;90(2):187-92.
273 Brodin H. Cervical pain and mobilization. Acta Belgica - Medica Physica. Apr. 1983;6(2):67-72.
274 Cilliers KI, Penter CS. Relative effectiveness of two different approaches to adjust a fixated segment in the treatment of facet syndrome in the cervical spine. JNMS. 1998;(1):1-5.
275 Eqwu MO. Relative therapeutic efficacy of some vertebral mobolization techniques in the management of unilateral cervical spondylosis: a comparitive study. Journal of Physical Therapy and Science. 2008;20:103-8.
276 van Schalkwyk R, Parkin-Smith GF. A clinical trial investigating the possible effect of the supine cervical rotatory manipulation and the supine lateral break manipulation in the treatment of mechanical neck pain: a pilot study. [see comment]. J Manipulative Physiol Ther. Jun. 2000;23(5):324-31. [pmid: 10863252].
277 Krauss J, Creighton D, Ely JD, et al. The immediate effects of upper thoracic translatoric spinal manipulation on cervical pain and range of motion: A randomized clinical trial. J Man Manip Ther. 2008;16(2):93-9. [pmid: 19119394].
278 Parkin-Smith GF, Penter CS. A clinical trial investigating the effect of two manipulative approaches in the treatment of mechanical neck pain: a pilot study. JNMS. 1998;(1):6-16.
279 Metcalfe S, Reese H, Sydenham R. Effect of high-velocity low-amplitude manipulation on cervical spine muscle strength: A randomized clinical trial. J Man Manip Ther. 2006;14(3):152-8.
280 Metcalfe S, Reese H, Sydenham R. The effect of high-velocity low-amplitude manipulation on cervical spine muscle strength: A randomized clinical trial. Orthop Div Rev. Sep. 2007;(4):31-7.
281 Korthals de Bos I, Hoving JL, van Tulder MW, et al. Cost effectiveness of physiotherapy, manual therapy, and general practitioner care for neck pain: economic evaluation alongside a randomised controlled trial. [see comment]. BMJ. Apr 26. 2003;326(7395):911. 2003. [pmid: 12714472].
282 Hoving JL, Korthals-de B I, De VH, et al. The effects and costs of manual therapy, physiotherapy and treatment by the general practitioner in neck disorders: A randomized clinical experiment. [Dutch]. Huisarts en Wetenschap. 2004;47(5):218-26.
283 Cleland J. Immediate effects of throacic spine manipulation in patients with neck pain: A randomized clinical trial. J Man Manip Ther. 2004;(12):162.
284 Kongsted A, Qerama E, Kasch H, et al. Neck collar, “act-as-usual” or active mobilization for whiplash injury? A randomized parallel-group trial. Spine (Phila Pa 1976). Mar 15. 2007;32(6):618-26. [pmid: 17413465].
285 Blikstad A, Gemmell H. Immediate effect of activator trigger point therapy and myofascial band therapy on non-specific neck pain in patients with upper trapezius trigger points compared to sham ultrasound: A randomised controlled trial. Clinical Chiropractic. Mar. 2008;11(1):23-9.
286 Yagci N, Uygur F, Bek N. Comparison of connective tissue massage and spray-and-stretch technique in the treatment of chronic cervical myofascial pain syndrome. Pain Clinic. 2004;16(4):469-74.
287 Cen SY, Loy SF, Sletten EG, et al. The effect of traditional Chinese Therapeutic Massage on individuals with neck pain. Clinical Acupuncture and Oriental Medicine. 2003;4(2-3):88-93.
288 Zaproudina N, Hanninen OO, Airaksinen O. Effectiveness of traditional bone setting in chronic neck pain: randomized clinical trial. J Manipulative Physiol Ther. Jul. 2007;30(6):432-7. [pmid: 17693333].
289 Sherman KJ, Cherkin DC, Hawkes RJ, et al. Randomized trial of therapeutic massage for chronic neck pain. Clin J Pain. Mar. 2009;25(3):233-8. [pmid: 19333174].
290 Zhang Y-Z, Wang X-H, Xing H-Y, et al. Mechanical effects of traction and massage therapy on cervical spondylopathy. Chinese J Clin Rehab. 2005;9(42):159-61.
291 Fernandez-de-Las-Penas C, Alonso-Blanco C, Fernandez-Carnero J, et al. The immediate effect of ischemic compression technique and transverse friction massage on tenderness of active and latent myofascial trigger points: A pilot study. J Bodywork Movement Ther. 2006;10(1):3-9.
292 Gemmell H, Miller P, Nordstrom H. Immediate effect of ischaemic compression and trigger point pressure release on neck pain and upper trapezius trigger points: A randomised, controlled trial. Clinical Chiropractic. Mar. 2008;11(1):30-6.
293 Hemmila HM. Bone setting for prolonged neck pain: a randomized clinical trial. J Manipulative Physiol Ther. Sep. 2005;28(7):508-15. [pmid: 16182025].
294 Hanten WP, Barrett M, Gillespie-Plesko M, et al. Effects of active head retraction with retraction/extension and occipital release on the pressure pain threshold of cervical and scapular trigger points. Physiotherapy Theory and Practice. 1997;13(4):285-91.
295 Hou CR, Tsai LC, Cheng KF, et al. Immediate effects of various physical therapeutic modalities on cervical myofascial pain and trigger-point sensitivity. Arch Phys Med Rehab. Oct. 2002;83(10):1406-14.
296 Fryer G, Hodgson L. The effect of manual pressure release on myofascial trigger points in the upper trapezius muscle. J Bodywork Movement Ther. 2005;9(4):248-55.
297 Meseguer AA, Fernandez-de-Las-Penas C, Navarro-Poza JL, et al. Immediate effects of the strain/counterstrain technique in local pain evoked by tender points in the upper trapezius muscle. Clinical Chiropractic. Sep. 2006;9(3):112-8. (24 ref) 2006;9(3):112-8.
298 Schiller L. Effectiveness of spinal manipulative therapy in the treatment of mechanical thoracic spine pain: a pilot randomized clinical trial. [see comment]. J Manipulative Physiol Ther. Jul. 2001;24(6):394-401. [pmid: 11514816].