# Unobtained Articles

New England Journal Study Shows OMT Benefits Patients with Back Pain. THE D. NOV. 1999;40(11):9-10.
Can neck manipulation cause stroke?. Medicine Today. 2003;4(7):9-10.
Alexander technique. Health Which. 1999;99(2):26-27.
Manipulative therapies. Focus on Alternative and Complementary Therapies. Jun. 2. 2007;12(2):131-132.
Assendelft WJ, Koes BW, Van Der, et al. The Effectiveness of Chiropractic for Treatment of Low Back Pain - An Update and Attempt at Statistical Pooling. Proceedings Of The Int'l Conference On Spinal Manipulation. 1996;(OCT):183.
Atkinson M. The relative effectiveness of combined spinal manipulative therapy and “action potential” therapy versus combined spinal manipulative therapy and placebo “action potential” therapy in the treatment of mechanical low back pain. Proceedings Of The World Federation Of Chiropractic Congress. 2001:6282.
Barlas P. Is acupuncture effective in the treatment of impingement syndrome?. Fact. 2006;11(1):44-44.
Barlas P, Kerr D. The good, the bad and the placebo TENS: acupuncture does not work for low back pain, or does it?. Focus on Alternative and Complementary Therapies. Jun. 2004;9(2):135-6. (2 ref) (2):135-136.
Baxter G D. Auriculotherapy: Effective in chronic and recurrent low back pain in the elderly? Commentary. Focus on Alternative and Complementary Therapies. 2008;13(3):198-199.
Baxter G D, Endres H. Chronic low back pain: acupuncture may be superior to conventional treatment?. Focus on Alternative and Complementary Therapies. Mar. 2008;13(1):32-4. (2 ref) (1):32-34.
Boyle E, Cote P, Grier A R, et al. Examining vertebrobasilar artery stroke in two Canadian provinces. [reprint in J Manipulative Physiol Ther. 2009 Feb;32(2 Suppl):S194-200; PMID: 19251064]. Spine. 2008;33(4 Suppl):S170-S175. [pmid: 18204389].
Breen A C, Meade T W. A post-hoc reconciliation of back pain subgroups revealed by the British chiropractic trial. Proceedings Of The 1998 International Conference On Spinal Manipulation. Fcer. 1998;(JUL):58.
Brennan P, Graham M, Hondras M, et al. Quality Control in a Randomized Clinical Trial Using Cellular Chemiluminescence. Proceedings Of The Int'l Conference On Spinal Manipulation. 1992;(MAY):125.
Bronfort G. A randomized clinical trial of spinal manipulation, exercise and; self-care for chronic neck pain. Proceedings Of The 2002 International Conference On Spinal Manipulation. 2002.
Bronfort G. A randomized clinical trial of spinal manipulation and exercise for chronic neck pain: a report on neck performance outcomes after 11 weeks and long-term effects on patient-rated outcomes. Proceedings Of The 1998 International Conference On Spinal Manipulation. Fcer. 1998:62-64.
Bronfort G. A Randomized Controlled Clinical Trial of Rehabilitative Exercise and Spinal Manipulation for Chronic Neck pain. Effects on neck pain and disability, functional health status, biomechanical neck dysfunction and somatoc-visceral symptoms. Proceedings of the 1998 International Conference on Spinal Manipulation. 1998:67-69.
Bronfort G. Chiropractic spinal adjustive therapy and exercise versus pharmacological treatment and exercise for chronic low back pain: a randomized clinical trial. Proceedings Of The Int'l Conference On Spinal Manipulation. 1992:181.
Bronfort G, Evans R L, Anderson A V, et al. Non-operative treatments for back-related leg pain: a second pilot study. Proceedings Of The World Federation Of Chiropractic Congress. 2001;6(May):283.
Bronfort G, Evans R, Nelson B, et al. A randomized controlled clinical trial of spinal manipulation and exercise for chronic neck pain. A report on neck performance outcomes after 11 weeks and long-term effects on patient-rated outcomes. Proceedings of the 1998 International Conference of Spinal Manipulation. 1998:62-68.
Browne W, Dyer S, Meade T W. Low Back Pain of Mechanical Origin: Randomized Comparison of Chiropractic and Hospital Outpatient Treatment. [Reprinted From BMJ]. J Chiropr. 1990;27(8):60-69.
Cai Guowei E T. [Clinical research in treatment of acute sciatica by needling yaoyangkuan (du3) deep]. Shanghai journal of acupuncture and moxibustion. 1996;15(2):8.
Cassidy J D, Boyle E, Cote P, et al. Risk of vertebrobasilar stroke and chiropractic care: results of a population-based case-control and case-crossover study. [see comment][reprint in J Manipulative Physiol Ther. 2009 Feb;32(2 Suppl):S201-8; PMID: 19251066]. Spine. 2008;33(4 Suppl):S176-S183. [pmid: 18204390].
Cassidy J D, Lopes A A, Yong-Hing K. The immediate effect of manipulation versus mobilization on pain and range of motion in the cervical spine: a randomized controlled trial. Journal of Manipulative and Physiological Therapeutics. 1993;16(4):279-280. [pmid: 8240497].
Chen B A I H, Ding J I A N, Li Minghui E T. [Effect of electrical acupuncture combined with traditional chinese drugs on fold microcirculation of lumbar intervertebral disc prolapse]. Journal of practical traditional chinese medicine. 2002;4(18):3.
Chen H L, Qiu X H, Yan X C. [Observation on therapeutic effect of electroacupuncture plus blood-letting puncture at Weizhong (BL 40) on acute lumbar disc herniation]. [Chinese]. Zhongguo Zhenjiu. 2009;29(2):123-125.
Chen M-R, Wang P, Cheng G, et al. The warming acupuncture for treatment of sciatica in 30 cases. Journal of Traditional Chinese Medicine. 2009;29(1):50-53. [pmid: 19514189].
Cherkin D C, Deyo R A, Battie M, et al. Chiropractic manipulation and McKenzie physiotherapy were not effective for low back pain. ACP Journal Club. 1999:v13042-April.
Cherkin D D. A randomized trial comparing chiropractic manipulation, mckenzie therapy and an education booklet for low back pain. Proceedings Of The Int'l Conference On Spinal Manipulation. 1996:103-104.
Cummings M, Ceccherelli F. No advantage in adding auriculotherapy to body acupuncture in cervical myofascial pain?. Focus on Alternative and Complementary Therapies. Sep. 3. 2006;11(3):213-214.
Cummings M, Witt C M, Brinkhaus B, et al. Acupuncture appears effective in chronic neck pain: Commentary. Focus on Alternative and Complementary Therapies. 2007;12(1):35-36.
Cummings T M. Acupuncture is better than massage for chronic neck pain. Focus on Alternative and Complementary Therapies. Dec. 2001;6(4):253-4. (3 ref) (4):253-254.
Devereaux M. Neck Pain. Medical Clinics of North America. 2009;93(2):273-284. [pmid: 19272509].
Doxet TT, Jarvis KB, Phillips RB. Cost Comparison of Low Back Care By Provider Type. Proceedings Of The Int'l Conference On Spinal Manipulation. 1996;(OCT):85-86.
Dutro C, Meeker W, Menke J, et al. The Efficacy of Flexion-Traction Manipulation and Inverted Gravity Traction for the Treatment of Idiopathic Low Back. Transactions of The Consortium For Chiropractic Research. 1986;(JUN.).
Eric L, Hurwitz D C PH D, et al. A randomized trial of manipulation versus mobilization for neck; pain: Outcomes from the UCLA Neck Pain Study. Proceedings Of The 2002 International Conference On Spinal Manipulation (Of The 2002 International Conference on Spinal Manipulation. 2002. OCT.
Ernst E, Dong H. Encouraging long-term results for acupuncture for neck and shoulder pain. Focus on Alternative and Complementary Therapies. Dec. 4. 2004;9(4):297-298.
Ernst E, Licciardone J C. Another negative trial of manipulative treatment for back pain. Focus on Alternative and Complementary Therapies. Mar. 2004;9(1):43-4. (7 ref) (1):43-44.
Foster N E. Does periosteal or intramuscular acupuncture help anxiety in patients with chronic neck and back pain?: Commentary. Focus on Alternative and Complementary Therapies. 2008;13(2):113-115.
Gemmell H. Treatment of Chronic Low-Back Pain with Low Force Manipulation. Chiropractic Journal of Australia. 1992;22(JUN):54-60.
Gert Bronfort D C PH D, Evans R, et al. Chiropractic, Medication, and Self-care for Neck Pain: From Pilot Study to Randomized Clinical Trial. Proceedings Of The 2002 International Conference On Spinal Manipulation. pp ,-.(OF The 2002 International Conference on Spinal Manipulation. 2002 OCT):,.
Gert Bronfort D C PH D, Roni Evans D C M S, et al. Implementing a randomized clinical trial of chiropractic, exercise and self-care for low back pain: challenges, implications and solutions. Proceedings Of The 2002 International Conference On Spinal Manipulation (Of The 2002 International Conference ON Spinal Manipulation. 2002. OCT.
Giebel G D, Edelmann M, Huser R. Die distorsion der halswirbelsaule: Fruhfunktionalle vs. ruhigstellende behandlung. Zentralbl Chir. 1997:122517-521.
Goodsells M, Lee. The effect of spinal mobilization on pain and range of motion in patients with low back pain. 12th Intern Congress World Confed Physical Therapy. 1995:30945.
Goossens ME, Evers S. Cost-effectiveness of treatment for neck and low back pain. 2000:399-419.
Guerriero D, Gappa J, Wagnon R. Comparative Effects of Manipulation and Physical Therapy on Motion in the Cervical Spine. Proceedings of The Int'l Conference on Spinal Mani. 1991;(APR):37-39.
Guo Y Q, Chen L Y, Fu W B, et al. [Clinically randomized controlled study on abdominal acupuncture for treatment of cervical spondylosis]. [Chinese]. Zhongguo Zhenjiu. 2007;27(9):652-656.
Haas M. McKenzie Therapy and Manipulation Have Similar Effects and Costs and Provide Only Marginally Better Outcomes than an Educational Booklet. Australian Journal of Physiotherapy. 1999:48. (45:(1)):48.
Haavik-Taylor H, Murphy B. Transient Modulation of Intracortical Inhibition Following Spinal Manipulation. Chiropractic Journal of Australia. 2007;37(3):106-116.
Hallegraeff H J, de Greef M, Winters J C, et al. Manipulative therapy and clinical prediction criteria in treatment of acute nonspecific low back pain. Perceptual & Motor Skills. 2009;108(1):196-208. [pmid: 19425461].
Han J I A N. [Therapeutic effect analysis of low back pain treated by acupuncture and moxibustion]. Journal of clinical acupuncture and moxibustion. 2003;19(8):20.
Harrison D E, Cailliet R, Harrison D D, et al. A new 3-point bending conservative method of restoring cervical lordosis: extension, distraction cervical traction combined with a transverse load at mid-neck. Proceedings Of The World Federation Of Chiropractic Congress. 2001;6(MAY):221.
He D, et al. Acupuncture treatment for sedentary female workers with chronic pain in the neck and shoulder region. Fact. 2003;8(4):503-503.
He T, He L. [Clinical observation on lumbar intervertebral disc herniation treated by traction combined with acupuncture]. [World Journal of Acupuncture Moxibustion]: World J Acup Moxi. 2004;14(2):11-14.
Helliwell PS, Cunliffe. Manipulation in low back pain. Physician. 1987;(April):187-188.
Hoiriis K T, Pfleger B, McDuffie F C, et al. A randomized clinical trial comparing chiropractic To conservative medical care for subacute low back pain. Proceedings Of The World Federation Of Chiropractic Congress. 2001;6(MAY):223.
Hong C-Z, Chen Y-C, Pon C H, et al. Immediate effects of various physical medicine modalities on pain threshold of an active myofascial trigger point. Journal of Musculoskeletal Pain. 1993;1(2):37-53.
Hsieh J. Functional Outcomes of Low Back Pain: Comparison of Four Treatment Groups in a Controlled Randomized Trial. Proceedings of The Int'l Conference on Spinal Mani. 1991;(APR):90-93.
Hu W Q, Xu S W. [Clinical observation on treatment of cervicogenic headache with tuina and acupuncture]. [Chinese]. Zhong Xi Yi Jie He Xue Bao. Journal of Chinese Integrative Medicine. 2005;3(4):310-311. [pmid: 16009114].
Huang S R, Shi Y Y, Zhan H S. [Control study on analgesic effect of single-point electroacupuncture on prolapse of lumbar intervertebral disc]. [Chinese]. Zhongguo Zhenjiu. 2006;26(5):319-321.
Hurst H C, Bolton J E. Clinically significant change: do statistical methods and patients' own perceptions agree?... European Chiropractors' Union Convention, Oslo Norway, Thursday 9 to Saturday 11 May 2002: 'Injury and trauma: can chiropractic manage it?'. European Journal of Chiropractic. 2. 2003;50(2):119.
Hurwitz E L. In Response: The Effectiveness of Physical Modalities Among Patients with Low Back Pain Randomized to Chiropractic Care: Findings From the UCLA Low Back Pain Study. Journal of Manipulative and Physiological Therapeutics. OCT. 2002;25(8):539-540.
Hurwitz E L, Rupert R. The effectiveness of physical modalities among patients with low back pain randomized to chiropractic care: findings from the UCLA low back pain study. [letter; comment]. J Manipulative Physiol Ther. 2002;25(8):538-540.
Hurwitz E L, Morgenstern H, Fei yu P H D, et al. Long-term effects of chiropractic versus medical care for low- back pain: 18-month follow-up in the UCLA Low-Back Pain Study. Proceedings Of The 2002 International Conference On Spinal Manipulation. pp ,-.(Of The 2002 International Conference on Spinal Manipulation. 2002 Oct):,.
Hurwitz E L, Morgenstern H, Harber P I, et al. The effectiveness of physical modalities among low-back-pain patients randomized to chiropractic care: Findings from the UCLA low-back pain study. Proceedings Of The World Federation Of Chiropractic Congress. 2001;6(MAY):224-225.
Hurwitz E L, Morgenstern H, Vassilaki M, et al. Chiropractic-related adverse reactions and their effects on satisfaction and clinical outcomes among patients enrolled in the UCLA neck pain study. WFC'S 7th Biennial Congress Conference Proceedings. May 1-3, 2003. 7th Edt. 2003:256-257.
Jarzem P, Harvey E J, Arcaro N, et al. Transcutaneous electrical nerve stimulation for non-acute low back pain. A randomized double-blind study of conventional, nu-wave, acupuncture-type and sham therapies. American Academy of Orthopaedic Surgeons 1997 Annual Meeting Scientific Program. 1997.
Jian L. Dr. Zhang Ren's experience in the acupuncture treatment of different diseases with the same therapeutic principle. Journal of Traditional Chinese Medicine. 2008;28(2):110-113. [pmid: 18652117].
Jiang S-Y, Yan J-T, Fang M, et al. Biomechanical changes associated with vertebral body in the process of cervical spondylosis treatment. [Chinese]. Journal of Clinical Rehabilitative.Tissue Engineering Research. 2009;13(11):2029-2032.
Jordan A, Bendix. Intensive Training, Physiotherapy, or Manipulation for Patients With Chronic Neck Pain. A Prospective Single-Blind Randomized Clinical Trial. Proceedings of The Int'l Conference on Spinal Mani. 1996;(OCT):109-110.
Jordan A, Bendix T, Nielsen H, et al. Intensive training, physiotherapy, or manipulation for patients with chronic neck pain. A prospective single-blind randomized clinical trial. Results of 2-year follow-up. Proceedings Of The 1998 International Conference On Spinal Manipulation. Fcer. 1998;(JUL):74-75.
Kastner U, Deutsch J, Lachner R. Chronic Headache in Children and Chiropractic Manipulation. Conference Proceedings of The Chiropractic Centennial Foundation. 1995;(JUL):286-287.
Kisiel C, Lindh C. Smartlindring med fysikalisk terapi och manuell akupunktur vid myofasciella nack- och skuldersmartor. Sjukgymnasten. 1996;12(Suppl):24-31.
Lakhani E, Nook B. The cervical spine, used both before and after treatment, to monitor patient progress. Proceedings Of The World Federation Of Chiropractic Congress. 2001;6(MAY):300-301.
Lawrence D J. Chiropractic care combined with heat improves pain and mobility better than heat alone. Focus on Alternative and Complementary Therapies. Dec. 4. 2006;11(4):315-316.
Lawrence D J, Haas M. Chiropractic treatment 3-4 times per week for 3 weeks beneficial for chronic unspecified low back pain. Focus on Alternative and Complementary Therapies. Mar. 1. 2005;10(1):43-44.
Li K, Wei D, Li J K. Acupuncture plus acupoint-injection for treatment of cervical spondylosis of vertebroarterial type. Journal of Traditional Chinese Medicine. 2008;28(4):243-244. [pmid: 19226889].
Liang J. Effect of comprehensive rehabilitative treatment on prolapse of lumbar intervertebral disc in 120 cases. Chinese Journal of Clinical Rehabilitation. 2002;6(12):1851.
Liang Y, Pi M, Dai W J. [Acupuncture Accompanied with Xie Ban (Oblique Traction) in Treating Lower Back Pain due to the Disorders of the Posterior Rami of the Spinal Nerves] (in Chinese). Zhen Jiu Lin Chuang Za Zhi. 2005;21(11):1-3.
Lim B W. Cervical manipulation: Let's do it right. Physiotherapy Singapore. 2003;6(2):26-27.
Lin Z W, Gao L P, Li J. [Clinical study on effect of embedding thread at Shenshu on postmenopausal osteoporosis](in Chinese). Zhen Jiu Lin Chuang Za Zhi. 2006;22(4):1-3.
Liu J, Zhang S. Treatment of protrusion of lumbar intervertebral disc by pulling and turning manipulations. Journal of Traditional Chinese Medicine. 2000;20(3):195-197. [pmid: 11038982].
Liu J-L, Kuang Z-Q. Effects of high-chest prone position manipulation therapy in cervical spondylopathy. [Chinese]. Chinese Journal of Clinical Rehabilitation. 2002;6(12):1760-1761.
Liu Z S, Zhao H, Xie L M. [Therapeutic effect of acupuncture on intermittent claudication of second retrograde lumbar spinal Stenosis] (in Chinese). Chinese Acupuncture & Moxibustion. 2004;24(7):461-464.
Long C R. Effectiveness of spinal manipulative therapy in the treatment of mechanical thoracic spine pain: a pilot randomized clinical trial... Schiller L. Effectiveness of spinal manipulative therapy in the treatment of mechanical thoracic spine pain: a pilot randomized clinical trial. J Manipulative Physiol Ther. 2001;24:394-401. Journal of Manipulative and Physiological Therapeutics. 2002 Oct; 25(8): 538.(2 ref) (8):538. [pmid: 11514816].
Lu L J, Jin Y D, Zheng R Y, et al. [The observe of clinical effect of treating lumbar intervertebral disc herniation by bone setting manipulation of different directions]. [Chinese]. Zhongguo Gushang. 2009;22(4):255-258. [pmid: 19408748].
Lu S. Scalp acupuncture therapy and its clinical application. Journal of Traditional Chinese Medicine. 1991;11(4):272-280. [pmid: 1839045].
Lu W, Xiong D-L, Jiang J. Clinical study on treatment of lumbar vertebral disc herniation with lumber Du channel electrical acupuncture. [Chinese]. Chinese Journal of Clinical Rehabilitation. 2002;6(8):1164-1165.
Lundeberg T. Acupuncture in headache. Cephalalgia, Supplement. 1999;19(25):65-68.
Luo J F. [Clinical observation on the therapeutic effect of acupuncture plus manual reposition for treatment of acute lumbar vertebral articular dyskinesia] (In chinese). World Journal of Acupuncture-Moxibustion. 2003;13(4):41-44.
Ma X P. Observations on the Curative Effect of Silver- needle Moxibustion on 54 Cases of Ankylosing Spondylitis] (in Chinese). Shanghai Journal of Acupuncture and Moxibustion. 2004;23(11):11-12.
MacPherson H, zThomas K. Traditional acupuncture for low back pain: developing high-quality evidence while maintaining the integrity of the treatment process. J Acupunct Assoc Chart Physiotherapists. 2008;2008(1):39-46.
Marx P, Puschmann H, Haferkamp G, et al. [Manipulative treatment of the cervical spine and stroke]. [German]. Fortschritte der Neurologie.-Psychiatrie. 2009;77(2):83-90. [pmid: 19221970].
Mathews J A, Mills S B, Jenkins V M, et al. Back pain and sciatica: Controlled trials of manipulation, traction, sclerosant and epidural injections. British Journal of Rheumatology. 1987;26(6):416-423. [pmid: 2961394].
Mazieres B. Acupuncture treatment of chronic low back pain: a short term controlled trial. Rev Rheum. 1981;48447.
McGregor M, Cramer G, Triano J, et al. Clinical Trials of Chiropractic Care: A Feasibility Study. Proceedings Of The Int'l Conference On Spinal Manipulation. 1990;(MAY):339-341.
McNamee K, Stacy T, Phillips R, et al. Telephone Follow-Up Questionnaire of the Subjects in a Prospective Randomized Trial of Chiropractic Manipulation, Corset, Massage and Transcutaneous Muscle Stimulatio. Proceedings Of The Int'l Conference On Spinal Manipulation. 1991;(APR):334.
McNamee K, Stacy T, Phillips R, et al. Subject Demographics and Pain Patterns in a Prospective Randomized Trial on Chiropractic Manipulation, Corset, Massage and Transcutaneous Muscle Stimulation in th. Proceedings Of The Int'l Conference On Spinal Manipulation. 1991;(APR):333.
Meeker W, Mootz R, Waldorf T, et al. Short-Term Pain, Function, and Health Perception Outcomes in a Randomized Clinical Trial Comparing Chiropractic, Physical Therapy, and Combined Treatments for Acut. Conference Proceedings of The Chiropractic Centennial Foundation. 1995;(JUL):289-290.
Mencke V M, Wieden T E, et al. Acupuncture of shoulder pain and low back pain: two double-blind studies. Akupunktur: Theor und Prax. 1988;16(4):204-215.
Menke J, Meeker W, Mootz R, et al. Outcomes of Injured Workers in a Clinical Trial Comparing Chiropractic and Medical Rehabilitation Treatment Regimens: A Preliminary Look. Proceedings Of The Int'l Conference On Spinal Manipulation. 1994;(JUN):31.
Mi Y Q. [Clinical Study on Electro-acupuncture plus Traction in Treating Cervical Disk Extrusion in 100 Cases](in Chinese). Zhen Jiu Tui Na Yi Xue. 2006;4(4):227-229.
Michalsen A. And the winner is ... Commentary. [German]. Forschende Komplementarmedizin. 2009;16(1):54-55. [pmid: 19297798].
Miron stano P H D, Rajiv sharma P H D, Mitchell haas D C. Long-term costs and cost-effectiveness for chiropractic and medical treatment for low back pain. Proceedings Of The 2002 International Conference On Spinal Manipulation. pp ,-.(Of The 2002 International Conference on Spinal Manipulation. 2002 OCT):,.
Moffett J K. The Chartered Society of Physiotherapy Annual Congress and Exhibition: Defining Practice, Friday, October 17 to Sunday, October 19 2003, International Convention Centre, Birmingham. The UK Back Pain Exercise and Manipulation (UK Beam) trial: preliminary results. The Chartered Society of Physiotherapy. 2003;163.
Murphy D. Is it safe to adjust the cervical spine in the presence of a herniated disc?. Dynamic Chiropractic. Jun 12. 2000;18(13):20-1. 32. 3. (18 ref) 1932;(13):20-21.
nfort G. A controlled trial of chiropractic spinal manipulation and exercise for low back pain: a pilot study. FCER Proceedings of the International Conference on Spinal Manipulation. 1990:62-65.
Niemistö L. Manipulative therapy, stabilizing exercises and specialist consultation as a treatment for chronic low back pain. Randomized controlled trial. Suomen Ortopedia ja Traumatologia. 2005;28(3):392-395.
Nobili C, Colombi A, Ambrosino G. Confronto a distanza dell'efficacia terapeutica dell'agopuntura e della TENS nel trattamento del low-back pain. Minerva Riflessoterapeutica e Laserterapeutica. 1985;(2):61-67.
Nyiendo J, Haas. Cost-Effectiveness of Chiropractic and Medical Treatment for Chronic, Recurrent Low Back Pain. Proceedings Of The Int'l Conference On Spinal Manipulation. 1996;(OCT):87.
Paatelma M, Kilpikoski S, Simonen R, et al. Orthopaedic manual therapy, McKenzie method or advice only for low back pain in working adults: A randomized controlled trial with one year follow-up. Journal of Rehabilitation Medicine. 2008;40(10):858-863. [pmid: 19242624].
Peng K Z, Xiang K W, Cui J. [Observation on therapeutic effect of intradermal needle combined with Tuina on lumbar disc herniation]. [Chinese]. Zhongguo Zhenjiu. 2008;28(12):894-896.
Pollard H. The Effect of Chiropractic Manipulation on the Cervical Spine of Women Aged Between 30 and 40 Suffering From Chronic Neck Pain. Australasian Chiropractic & Osteopathy. NOV. 1997;6(3):99.
Pollard H, Thomson P. The effect of chiropractic manipulation on the cervical spine of women aged between 30 and 40 suffering from chronic neck pain. Proceedings Of The 1998 International Conference On Spinal Manipulation. Fcer. 1998;(JUL):181-182.
Pope M H M L. A prospective randomized three week trial of spinal manipulation, transcutaneous muscle stimulation, massage and corset in the treatment of subacute low back pain. Second World Chiropractic Congress, London, England; May 24-29, 1993. Journal of Manipulative and Physiological Therapeutics. 1994;17(4):287-288.
Pope M H, Phillips R B, MacDonald L, et al. A prospective randomized trial of manipulation, corset, massage and transcutaneous muscle stimulation in the management of sub-acute low back pain. Vermont Rehabilitation Engineering Center. 1990.
Provinciali L, Baroni M, Illuminati L, et al. Multimodal treatment to prevent the late whiplash syndrome. Scand.J Rehabil.Med. 1996;28(2):105-111. [pmid: 8815995].
Qiao J-L, Wang J-R, Gu Q, et al. A randomized controlled observation of acupotomology in treating syndrome of third lumbar vertebra transverse process. [Chinese]. Chinese Journal of Clinical Rehabilitation. 2003;7(26):3606-3607.
Quinn F, Baxter D, Hughes C. Reflexology in the treatment of low back pain: a pilot RCT. 12th Annual Symposium on Complementary Health Care -- Abstracts. 19th-21st September 2005. Exeter, UK. Focus on Alternative and Complementary Therapies. 2005;10(Supplement 1):44. 44.
Rowley N C, Matthews R. The relative efectiveness of single dry needle insertion compared to multiple fanning dry needle insertion in the treatment of myofascial pain syndrom. Proceedings Of The World Federation Of Chiropractic Congress. 2001;6(MAY):316.
Rupert R. Chiropractic adjustments in the treatment of low back pain: preliminary results of a controlled clinical trial in Egypt. Biomechanics Conference on the Spine. 1983;14(Nov):315-328.
Rupert R, WAGNON R, Thompson P. Chiropractic adjustments in the treatment of low back pain: preliminary results of a controlled clinical trial in Egypt [reprint]. International Review of Chiropractic. 1985;41(1):58-59.
Salsali M, Pouresmaeil Z, Faghiehzadeh S, et al. Effects of accupressure on low back pain [Farsi]. Hayat: The Journal of Tehran Faculty of Nursing & Midwifery. Winter. 2004;9(19):11p. (19 ref) (19):11p.
Sanders G T R M. The effect of spinal adjustive manipulation on subjects with acute low back pain: A comparison of visual analog pain scores and serum beta endorphin levels. Symposium of the Pacific Consortium for Chiropractic Research. Monterey, California. July 2. 1989. Journal of Manipulative and Physiological Therapeutics 1990;13(1):58.
Steurer J. Alexander technique: An effective therapy for patients with chronic back pain. [German]. Schweizerische Rundschau fur Medizin - Praxis. 2009;98(5):290-291.
Stoddard A. Manipulation for low backache. Rheumatism [England]. 1960;16(1):20-24.
Stokke O. A Randomized Comparison of Chiropractic and Physiotherapy Treatment for Neck Pain of Functional (Mechanical) Origins: A Controlled Clinical Trial. Conference Proceedings of The Chiropractic Centenn. 1995;(JUL):372-373.
Sun G P. [Clinical observation on auricular point magnetotherapy for treatment of senile low back pain]. Zhongguo zhen jiu = Chinese acupuncture & moxibustion. 2007;27(2):112-114.
Talcott T N. Talcott's CRT syndrome. Dig Chiropractic Econ. 1987;30(3):58. 126.
Tanaka D. Randomized controlled trial of chiropractic manipulation versus medical treatment for chronic neck pain. Proceedings Of The 1998 International Conference On Spinal Manipulation. Fcer. 1998:86-88.
Teggiachi M, Horacio M. Low back pain and lumbar sciatic pain treatment with electroacupunture. [Spanish]. Revista Internacional.de Acupuntura. 2008;2(3):195-198.
Thomas K J, MacPherson H, Thorpe L, et al. Randomized controlled trial of a short course of traditional acupuncture compared with usual care for persistent non-specific low back pain. J Acupunct Assoc Chart Physiotherapists. 2007;2007(3):47-56.
Thomas K, MacPherson H, Ratcliffe J. A short course of acupuncture is a cost-effective intervention for low back pain in primary care. Results from a pragmatic randomised controlled trial [abstract]. Proceedings of the First Annual Meeting of the Health Technology Assessment International (HTAi). 2004 May 30 - June 2. 2004:174.
Triano J. A Randomized Clinical Trial for Treatment of Chronic Mechanical Low Back Pain. Proceedings Of The Int'l Conference On Spinal Manipulation. 1992;(May):183-184.
Triano J. Changes in paraspinal muscle balance in low-back pain as a consequence of SMT and exercise treatment. International Review of Chiropractic. 1981;35(3):40.
Triano J, McGregor M, Hondras M, et al. A Randomized Controlled Clinical Trial of Manipulation for Chronic Low Back Patients. Transactions of The Consortium For Chiropractic Re. 1993;8TH(Jun):172.
Van Tulder M W. Review of Prolotherapy injections, saline injections, and exercises for chronic low-back pain: a randomized trial. (Yelland,M; et al). Fact. 2004;9(2):137-138.
van der V, Hogg-Johnson S, Bayoumi A M, et al. Identifying the best treatment among common nonsurgical neck pain treatments: a decision analysisanalysis. [reprint in J Manipulative Physiol Ther. 2009 Feb;32(2 Suppl):S209-18; PMID: 19251067]. Spine. 2008;33(4 Suppl):S184-S191. [pmid: 18204391].
van Tulder M, Underwood M. Spinal manipulation alone or followed by exercise more effective than usual care for back pain. Focus on Alternative and Complementary Therapies. Jun. 2. 2005;10(2):131-133.
Vasseljen O, Johansen B M, Westgaard R H. The effect of pain reduction on perceived tension and EMG-recorded trapezius muscle activity in workers with shoulder and neck pain. Scand.J Rehabil.Med. 1995;27(4):243-252. [pmid: 8650509].
View Citation. Abstract of Acupuncture: evidence for its use in chronic low back pain (Henderson, H.). DARE, The Cochrane Library. 2005;2005.
View Citation. Acupuncture for back pain. Fact. 2005;10(2):145-145.
View Citation. Acupuncture alleviates low back pain in pregnancy. Fact. 2004;9(4):326-326.
View Citation. Chronic low-back pain: Comparison of acupuncture, therapeutic massage, and self-care education.(Brief article). Life Sciences and Biotechnology Update. 2000.
View Citation. Abstract of Forty-six cases of the nerve root-involved cervical spondylopathy treated by needling the Sitian points (Dong,H; et al). J Chin Med. 2006:8154-54.
Von Bubnoff A. Acupuncture activates the brain. news@nature.com. 2005.
Wang L Q. [Observation on therapeutic effects of scraping therapy and warming acupuncture-moxibustion on 50 cases of fasciitis of back muscles]. Zhongguo Zhen Jiu. 2006;26(7):478-480. [pmid: 16903597].
Wenzel K W. [[Acupuncture: what is the outcome of the Gerac Studies?--comment on DMW 4/2005]. [German]. Deutsche Medizinische Wochenschrift. 2005;130(24):1520. [pmid: 15942849].
White A R. Acupuncture or physiotherapy for neck pain? Similar success rates. Focus on Alternative and Complementary Therapies. 1999;4(1):13-14.
White A R. Effectiveness for treating back pain: acupuncture compared with transcutaneous electrical nerve stimulation. Focus on Alternative and Complementary Therapies. Dec. 1999;4(4):187-8. (2 ref) (4):187-188.
Whittingham W, English R. The Efficacy of Cervical Manipulation (Toggle Recoil) for Chronic Headaches with Upper Cervical Joint Dysfunction. Conference Proceedings of The Chiropractic Centennial Foundation. 1995;(Jul):297-298.
Whittingham W, Dacosta C, McCrossin P, et al. Randomized Placebo Controlled Clinical Trial of Efficacy of Chiropractic Treatment for Chronic Cervicogenic Headaches. Proceedings Of The World Federation Of Chiropractic Congress. 2001;6(May):238-239.
Williamson A, Till G. The relative effectiveness of spinal manipulative therapy (SMT) and a non-steroidal anti-inflammatory drug compared to SMT and placebo in the treatment of cervical facet syndrome. WFC'S 7TH Biennial Congress Conference Proceedings. May 1-3, 2003. 7th Edt. 2003:266.
Wu Y C, Wand C M, et al. Treatment of acute lumbar sprain with single acupoint: a RCT. Zhen Jiu Tui Na Yi Xue. 2005;2(4):56-59.
Wu Y C, Zhang B M, Wang C M, et al. [Observations on the Short-term and Long-term Effects of Point Houxi (SI 3) Electroacupuncture on Acute Lumbar Sprain](in Chinese). Zhen Jiu Tui Na Yi Xue. 2006;4(6):356-359.
Xin B Y. [Observation on Therapeutic Effect of Electro-acupuncture in the Treatment of Chronic Low Back Pain: A Report of 30 Cases] (in Chinese). Zhen Jiu Tui Na Yi Xue. 2005;3(4):35-36.
Xue B, Fan L, Hu L. Clinical observation on cervical spondylopathy vertebroarterial type treated by electro-acupuncture. Journal of Traditional Chinese Medicine. 2007;27(1):39-42. [pmid: 17393625].
Xue P W. [Clinical observation on deeply needling Ciliao (BL 32) for treatment of prolapse of lumbar intervertebral disc]. [Chinese]. Zhongguo Zhenjiu. 2007;27(3):182-184.
Yamashita H. Are the effects of electro-acupuncture on low back pain equal to those of TENS?. Focus on Alternative and Complementary Therapies. Dec. 2001;6(4):254-5. (2 ref) (4):254-255.
Yan J Y. [Comparison of Therapeutic Effects Between Acupuncture plus Sacral Injection and Simple Acupuncture for Lumbar Intervertebral Disc Herniation](in Chinese). Zhen Jiu Tui Na Yi Xue. 2007;5(3):169-170.
Yang Q J. [Clinical Observation on the Treatment of Lumbar Intervertebral disc Protrusion with Electroacupuncture, TDP plus Tuina] (in Chinese). Zhen Jiu Tui Na Yi Xue. 2005;3(4):37-39.
Yao-chi W, Bi-meng Z, Chong-miao W, et al. [Observation on short-term and long-term therapeutic effects of electroacupuncture at Houxi (SI 3) on acute lumbar sprain]. Zhongguo Zhen. Jiu. 2007;27(1):3-5. [pmid: 17378192].
Ye J X. Therapeutic Observation on Treatment of 68 Cases of Prolapse of Lumbar Intervertebral Disc with Lumber Vertebral Traction plus Ding's Rolling Technique](in Chinese). Zhen Jiu Tui Na Yi Xue. 2007;5(5):284-287.
Young K, Dhami M. The Efficacy of Cervical Manipulation as Opposed to Pharmacological Therapeutics in the Treatment of Migraine Patients. Transactions of The Consortium For Chiropractic Research. 1987;(Jun.).
Zhang Wei-Hua E T. Long Needle Acupuncture Plus Cupping in Treating Primary Sciatica. International journal of acupuncture. 1997;8(3):318-321.
Zhang J H, Fan J Z, QI Z Q. [Effect of floating acupuncture on the processes transverses of vertebrae lumbales III syndrome] (in Chinese). Zhong Guo Kang Fu Li Lun Yu Shi Jian. 2005;11(9):752-753.
Zhi L X, Feng C W, Tu C Y. [Controlled randomized trial on therapeutic effects of acupotomy-injection combined with Feng's spinal manipulation (FSM) for cervical spondylotic radiculopathy] [Chinese]. Zhongguo Gushang. 2008;21(6):421-424.
Zhou G H. Clinical evaluation of three different recovery treatments on herniation of lumbar intervertebral disc. Chinese Journal of Rehabilitation Theory & Practice. 2003;9(11):687-688.
Zhou J W, Jiang Z Y, Ye R B, et al. [Controlled study on treatment of cervical spondylopathy of the nerve root type with acupuncture, moxibustion and massage as main]. [Chinese]. Zhongguo Zhenjiu. 2006;26(8):537-543.
Zhou X B, Jin T, Shi R H, et al. [Controlled clinical trials on the treatment of lumbar disk herniation by Dingweiban and Xieban manipulation]. [Chinese]. Zhongguo Gushang. 2008;21(12):895-898. [pmid: 19146155].
Zou Y C. Treatment of repetitive strain injury with acupuncture combined with behavior medicine therapy. Zhen Jiu Tui Na Yi Xue. 2004;2(4):44-47.