# Appendixes

Appendix A Exact Search Strings

Appendix B Sample Data Abstraction Forms

Appendix C Evidence Tables

Appendix D List of Excluded Studies

Appendix E Peer Reviewers & Technical Expert Panel

Appendix F Quality Assessment Forms

Appendix G Quality Assessment Data

Appendix H Unobtained Articles

Appendix I Summary Tables