# Quality Assessment Data

Table 1.1 Low Back Pain - Acupuncture

Study ID | Q1. Randomization Adequate? | Q2. Treatment Allocation Concealed? | Q3. Groups similar at baseline re: prognostic indicators | Q4. Patient blinded to the intervention? | Q5. Care provider blinded to the intervention? | Q6. Outcome assessor blinded to the intervention? | Q7. Co-interventions avoided or similar? | Q8. Compliance acceptable in all groups | Q9. Dropout rate described and acceptable? | Q10. Timing of the outcome assessment in all groups similar? | Q11. Analysis includes an intention-to-treat analysis? | Q12. Reports of the study free of suggestion of selective outcome reporting? | Q13. Is this study free of any other bias? | Total “Yes”
Araki 2001 1 | Yes | Yes | Yes | Yes | No | Yes | Not clear | Yes | Yes | Yes | Yes | Yes | Not clear | 10
Brinkhaus 2006 2 | Yes | Yes | Yes | Yes | No | Not clear | Not clear | Not clear | Yes | Yes | Yes | Yes | Not clear | 8
Cao 2001 3 | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | No | Not clear | Not clear | Not clear | Not clear | 0
Carlsson 2001 4 | Not clear | Not clear | Yes | No | No | Yes | No | No | Yes | Yes | Yes | Yes | Not clear | 6
Ceccherelli 2002 5 | Yes | Yes | Yes | Not clear | Yes | No | Yes | Not clear | Yes | Yes | Yes | Yes | Not clear | 9
Ceccherelli 2003 6 | Not clear | Not clear | Not clear | No | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | 7
Chen 1998 7 | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Not clear | 2
Chen 2005 8 | Yes | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 4
Chen 2007 9 | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 3
Cherkin 2001 10 | Yes | No | Yes | No | No | No | Not clear | Yes | Yes | Yes | Yes | No | Not clear | 6
Cherkin 2009 11 | Not clear | Not clear | Not clear | No | No | Yes | Yes | Yes | Yes | Yes | Yes | No | Not clear | 6
Chu 2004 12 | No | No | Yes | Yes | No | No | Yes | Not clear | Yes | Yes | Yes | Yes | No | 7
Coan 1980 13 | Not clear | Not clear | No | No | Not clear | Not clear | Not clear | Yes | Yes | Not clear | Not clear | Yes | Not clear | 3
Cui 2004 14 | Yes | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 4
Ding 1998 15 | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 3
Ding 2002 16 | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 3
Edelist 1976 17 | Not clear | Not clear | Not clear | Yes | No | Yes | Not clear | Not clear | Not clear | Not clear | Not clear | No | Not clear | 2
Eisenberg 2007 18 | Yes | Yes | Yes | No | No | Yes | Not clear | Not clear | Yes | Yes | Yes | Yes | Not clear | 8
Fu 2006 19 | Not clear | Yes | Yes | Not clear | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | 3
Garvey 1989 20 | Yes | No | Yes | Yes | Yes | Yes | Yes | No | No | Yes | Not clear | No | Not clear | 7
Giles 1999 21 | Not clear | Not clear | No | No | No | Not clear | Not clear | No | No | Not clear | No | Yes | No | 1
Giles 2003 22 | Yes | Yes | No | No | No | Yes | No | No | No | Yes | Yes | No | Not clear | 5
Grant 1999 23 | Yes | Yes | No | No | No | Yes | Not clear | Not clear | Yes | Yes | No | Yes | No | 6
Gunn 1980 24 | Yes | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | Yes | No | Not clear | Yes | Not clear | 4
Guo 2005 25 | No | Not clear | Yes | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Yes | Yes | Not clear | Not clear | 4
Haake 2007 26 | Yes | Yes | Yes | Yes | No | Yes | Not clear | Not clear | Yes | Yes | Yes | Yes | Yes | 10
He 1997 27 | Not clear | No | Not clear | Yes | No | No | Not clear | Not clear | No | Yes | Yes | Yes | Not clear | 4
He 2007 28 | No | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 3
Hirota 2006 29 | Yes | Not clear | Not clear | Yes | No | Not clear | No | Yes | Not clear | Yes | Not clear | Yes | No | 5
Hodgson 2006 30 | Yes | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear
Hollisaz 2006 31 | Not clear | Not clear | Yes | Not clear | No | Not clear | Not clear | No | No | Yes | Not clear | No | Not clear | 2
Huang 2006 32 | Yes | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Yes | Yes | Not clear | Not clear | 6
Huang 2006 33 | Yes | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | No | Not clear | No | 4
Inoue 2000 34 | Yes | Yes | Not clear | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | 10
Inoue 2001 35 | Yes | Yes | Not clear | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | 10
Inoue 2006 36 | Yes | Yes | Yes | Yes | No | Yes | Not clear | Not clear | Yes | Yes | Yes | Yes | Not clear | 9
Itoh 2004 37 | Yes | Not clear | Yes | Yes | No | Yes | Not clear | Not clear | Yes | Yes | No | Yes | No | 7
Itoh 2006 38 | Yes | Yes | Yes | Yes | No | Yes | Not clear | Not clear | Yes | Yes | No | Yes | No | 8
Itoh 2009 39 | Not clear | Not clear | Yes | No | No | Not clear | Yes | Yes | Yes | Yes | Not clear | Yes | Not clear | 6
Jia 2004 40 | Yes | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Yes | Not clear | Not clear | 5
Kawase 2006 41 | Yes | Yes | Yes | Yes | Not clear | Not clear | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | 10
Kennedy 2008 42 | Yes | Yes | No | No | No | Yes | Not clear | Yes | Yes | Yes | Yes | Yes | Not clear | 8
Kerr 2003 43 | No | No | Yes | Yes | No | Not clear | Yes | No | No | Yes | Not clear | Not clear | Not clear | 4
Kittang 2001 44 | No | Not clear | No | Not clear | Not clear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | 7
Kurosu 1979 45 | Not clear | Not clear | Not clear | No | No | Not clear | Not clear | Yes | Not clear | Yes | Not clear | Yes | Not clear | 3
Kwon 2007 46 | Yes | No | Yes | Yes | No | Not clear | Not clear | Yes | Yes | Yes | Yes | No | Not clear | 7
Lai 2004 47 | Yes | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 4
Lee 2007 48 | Not clear | Not clear | Not clear | Yes | No | No | Not clear | Not clear | Yes | Yes | Not clear | No | Not clear | 3
Lehmann 1983 49 | Not clear | Not clear | Not clear | No | No | Not clear | Not clear | No | No | Yes | Not clear | No | Not clear | 1
Leibing 2002 50 | Not clear | Not clear | Yes | Not clear | No | Not clear | No | No | No | Yes | Not clear | No | Not clear | 2
Li 1997 51 | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 2
Li 2005 52 | Not clear | Not clear | Yes | Yes | No | No | Yes | Not clear | No | Yes | No | Not clear | Not clear | 4
Li 2006 53 | Yes | Not clear | Yes | Not clear | Not clear | No | Yes | Not clear | Yes | Yes | Yes | Not clear | Not clear | 6
Lian 2005 54 | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Yes | Not clear | No | Not clear | 3
Liang 2008 55 | Not clear | Not clear | Yes | No | Not clear | Yes | Not clear | Not clear | Yes | Yes | Not clear | Yes | Not clear | 5
Long 2000 56 | Not clear | Not clear | Not clear | No | No | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | Yes | No | 2
Luo 2007 57 | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | 0
Macdonald 1983 58 | Not clear | Not clear | Not clear | No | No | Yes | Not clear | Not clear | Not clear | Not clear | No | Yes | Not clear | 2
Mencke 1988 59 | Yes | Not clear | Yes | Yes | Not clear | Yes | Yes | Not clear | Yes | Yes | No | Yes | Yes | 9
Mendelson 1978 60 | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | No | No | Yes | Not clear | No | Not clear | 1
Mendelson 1983 61 | Not clear | Not clear | Yes | Yes | Not clear | Yes | Not clear | Not clear | Yes | Yes | No | Yes | Not clear | 6
Meng 2003 62 | Yes | Yes | Yes | No | No | Not clear | Yes | Not clear | Yes | Yes | Yes | No | Not clear | 7
Molsberger 2002 63 | Not clear | No | Yes | No | No | No | Not clear | No | No | Yes | Yes | Not clear | Not clear | 3
Mu 2007 64 | Yes | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Yes | Not clear | Not clear | Not clear | 5
Peng 2006 65 | No | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | No | Not clear | No | 3
Qu 2006 66 | No | No | Yes | No | No | No | Not clear | Not clear | Not clear | Yes | No | Not clear | Not clear | 2
Sakai 1998 67 | Not clear | Not clear | No | No | No | Not clear | Not clear | Not clear | No | No | Not clear | Not clear | Not clear | 0
Sakai 2001 68 | Yes | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Yes | No | Not clear | Not clear | 8
Sator-Katzenschlager 2004 69 | Yes | Yes | No | Yes | No | Yes | Not clear | Yes | Yes | Yes | Yes | Yes | Not clear | 9
She 2008 70 | No | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 3
Takeda 2001 71 | Yes | Not clear | Not clear | Yes | No | No | Not clear | Yes | Yes | Yes | Not clear | Not clear | Not clear | 5
Tang 2008 72 | No | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | No | Not clear | No | 3
Thomas 1994 73 | Not clear | Not clear | Yes | No | No | No | Not clear | Yes | Yes | Yes | Not clear | No | Not clear | 4
Thomas 2005 74 | Yes | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Yes | No | Yes | Not clear | 9
Tsui 2004 75 | Not clear | Not clear | Yes | Yes | Not clear | Yes | Not clear | Not clear | Yes | Yes | Not clear | Yes | Not clear | 6
Tsukayama 2002 76 | Yes | No | Yes | Not clear | No | Not clear | Yes | Yes | Yes | Yes | Not clear | Yes | Not clear | 7
Wang 2004 77 | Not clear | Not clear | Not clear | No | No | Not clear | Not clear | Not clear | Not clear | Yes | No | Yes | Not clear | 2
Wang 2004 78 | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Not clear | Not clear | Not clear | Not clear | 2
Wang 2005 79 | Yes | Not clear | Yes | Not clear | Not clear | Yes | Yes | Not clear | No | Yes | Yes | Not clear | Not clear | 6
Wang 2007 80 | Yes | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Yes | Yes | Not clear | Not clear | 6
Witt 2006 81 | Yes | Yes | Yes | No | No | Yes | Not clear | Not clear | Yes | Yes | No | Yes | Not clear | 7
Wu 2004 82 | Yes | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | No | 4
Wu 2004 83 | No | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 3
Wu 2007 84 | Yes | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 4
Xia 1997 85 | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 2
Yao 2007 86 | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 3
Ye 2002 87 | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 2
Ye 2004 88 | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 2
Yeung 2003 89 | Not clear | Not clear | Yes | No | No | Not clear | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | 7
Yu 1997 90 | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 2
Yuan 2006 91 | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | 0
Yuan 2009 92 | Yes | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Yes | Yes | No | Not clear | 9
Zeng 2007 93 | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 2
Zhang 2002 94 | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | No | Not clear | No | Yes | Not clear | Not clear | Not clear | 2
Zhang 2002 95 | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | No | Not clear | No | Yes | Not clear | Not clear | Not clear | 1
Zhang 2007 96 | Yes | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 4
Zhang 2008 97 | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Yes | No | Not clear | Not clear | 4
Zhong 2006 98 | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 2
Zhou 1998 99 | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 3
Zhou 2004 100 | Yes | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 4
Zhou 2005 101 | Yes | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 4
Zhou 2006 102 | Yes | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Yes | Not clear | Not clear | No | 5
Zhu 2003 103 | Yes | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 4

Table 1.2 Low Back Pain - Manipulation

Study ID | Q1. Randomization Adequate? | Q2. Treatment Allocation Concealed? | Q3. Groups similar at baseline re: prognostic indicators | Q4. Patient blinded to the intervention? | Q5. Care provider blinded to the intervention? | Q6. Outcome assessor blinded to the intervention? | Q7. Co-interventions avoided or similar? | Q8. Compliance acceptable in all groups | Q9. Dropout rate described and acceptable? | Q10. Timing of the outcome assessment in all groups similar? | Q11. Analysis include an intention-to-treat analysis? | Q12. Reports of the study free of suggestion of selective outcome reporting? | Q13. Is this study free of any other bias? | Total “Yes”
Alaksiev 1996 104 | Not clear | Not clear | Yes | No | No | No | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Not clear | 3
Alaksiev 1996 104 | Not clear | Not clear | Yes | No | No | No | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Not clear | 3
Bronfort 1989 105 | Not clear | Not clear | No | No | No | No | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Not clear | 2
Bronfort 1989 105 | Not clear | Not clear | No | No | No | No | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Not clear | 2
Buerger 1980 106 | Not clear | Not clear | Yes | Yes | No | Yes | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | 3
Buerger 1980 106 | Not clear | Not clear | Yes | Yes | No | Yes | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | 3
Cherkin 1998 107 | Not clear | No | No | Not clear | Not clear | Not clear | Yes | Yes | Yes | Yes | Yes | No | Not clear | 5
Childs 2004 108 | Yes | Yes | Yes | No | No | Yes | Yes | Not clear | No | Yes | Yes | Yes | No | 8
Cote 1994 109 | Yes | Not clear | Yes | No | No | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | Yes | No | 4
Dai 2006 110 | No | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | Not clear | Yes | No | Not clear | No | 3
Evans 1978 111 | Not clear | Not clear | Yes | No | No | Not clear | Yes | Yes | Yes | Yes | Yes | No | Not clear | 6
Giles 1999 21 | Not clear | Not clear | No | No | No | Not clear | Not clear | No | No | Not clear | No | Yes | No | 1
Haas 2004 112 | Yes | Yes | No | No | No | Not clear | No | Yes | Yes | Yes | Yes | Yes | Not clear | 7
Hadler 1987 113 | Not clear | No | Yes | Yes | No | Yes | Not clear | Yes | Yes | Yes | No | Yes | Not clear | 7
Herzog 1991 114 | Not clear | Not clear | Not clear | No | No | Yes | Yes | Yes | No | Yes | No | Yes | Not clear | 5
Hoehler 1981 115 | Not clear | Not clear | Yes | No | No | Yes | Not clear | Not clear | Not clear | Not clear | No | Yes | Not clear | 3
Hoehler 1981 115 | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Not clear | 3
Hoiriis 1999 116 | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | 0
Hoiriis 2004 117 | No | No | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | No | Not clear | 8
Hondras 2009 118 | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | 11
Hsieh 2002 119 | Not clear | Not clear | Yes | No | No | Not clear | Not clear | No | Yes | Yes | Yes | No | Not clear | 4
Lalanne 2009 120 | Not clear | Not clear | Yes | No | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | 1
Mathews 1988 121 | Not clear | Not clear | Not clear | No | No | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Not clear | 2
Mohseni-Bandpei 2006 122 | Not clear | Not clear | Yes | No | No | Not clear | Not clear | Not clear | No | Yes | Not clear | No | Not clear | 2
Morton 1999 123 | Yes | Not clear | Yes | No | No | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Not clear | 4
Pope 1994 124 | Not clear | Yes | Yes | No | No | Yes | Not clear | No | Not clear | Yes | No | Yes | Not clear | 5
Postacchini 1988 125 | Not clear | Not clear | Yes | No | No | Not clear | Yes | Yes | Yes | Yes | Not clear | Yes | Not clear | 6
Rasmussen 1979 126 | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Yes | Not clear | Not clear | No | Not clear | 2
Rasmussen 2008 127 | Not clear | Not clear | Not clear | No | No | Yes | Yes | Yes | Yes | Yes | Yes | No | Not clear | 6
Rupert 1985 128 | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Not clear | Not clear | No | Not clear | 2
Sanders 1990 129 | Not clear | No | Yes | Not clear | Not clear | Yes | Not clear | Yes | Yes | Yes | Yes | Yes | Not clear | 7
Shearar 2004 130 | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | 1
Triano 1995 131 | Yes | No | Yes | No | No | Yes | Yes | No | No | Yes | No | Yes | Not clear | 6
UK BEAM Trial Team 2004 132 | Not clear | Not clear | Yes | No | No | Not clear | Not clear | Not clear | Not clear | Yes | Yes | Yes | Yes | 5
Waagen 1986 133 | No | Not clear | Not clear | Yes | No | Yes | Yes | No | No | Yes | Not clear | Yes | Not clear | 5
Zhang 2008 134 | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Yes | No | Not clear | Not clear | 4

Table 1.3 Low Back Pain - Mobilization

Study ID | Q1. Randomization Adequate? | Q2. Treatment Allocation Concealed? | Q3. Groups similar at baseline re: prognostic indicators | Q4. Patient blinded to the intervention? | Q5. Care provider blinded to the intervention? | Q6. Outcome assessor blinded to the intervention? | Q7. Co-interventions avoided or similar? | Q8. Compliance acceptable in all groups | Q9. Dropout rate described and acceptable? | Q10. Timing of the outcome assessment in all groups similar? | Q11. Analysis includes an intention-to-treat analysis? | Q12. Reports of the study free of suggestion of selective outcome reporting? | Q13. Is this study free of any other bias? | Total “Yes”
Aleksiev 1995 135 | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | No | Not clear | 2
Chiradejnant 2002 136 | Not clear | Not clear | Not clear | No | No | Yes | Not clear | Yes | Yes | Yes | Yes | Not clear | Not clear | 5
Chiradejnant 2003 137 | Yes | Yes | Not clear | No | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | 9
Cote 1994 109 | Yes | Not clear | Yes | No | No | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | Yes | No | 4
Goodsell 2000 138 | No | Not clear | Not clear | No | No | Yes | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Not clear | 3
Hadler 1987 113 | Not clear | No | Yes | Yes | No | Yes | Not clear | Yes | Yes | Yes | No | Yes | Not clear | 7
Hanrahan 2005 139 | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Not clear | 2
Hemmila 1997 140 | Yes | Not clear | Yes | No | No | Not clear | Yes | No | No | Yes | Not clear | Yes | Not clear | 6
Hemmila 2002 141 | Yes | Yes | Yes | No | No | Yes | No | Yes | Yes | Yes | Yes | No | Not clear | 8
Konstantinou 2007 142 | Yes | Not clear | Not clear | No | No | Yes | Not clear | Not clear | Yes | Yes | Not clear | Yes | No | 5
Li 2006 143 | Yes | Yes | Yes | Yes | Not clear | Yes | Yes | Not clear | Yes | Yes | Yes | Not clear | Yes | 10
Lopez 2007 144 | Yes | Not clear | No | No | No | Yes | Not clear | Yes | Yes | Yes | Yes | Yes | Yes | 8
Mackawan 2007 145 | Not clear | Not clear | No | No | No | Not clear | Not clear | Yes | Yes | Yes | Yes | Yes | Not clear | 5
Powers 2008 146 | Not clear | No | Yes | No | No | Yes | Not clear | Not clear | No | Yes | Not clear | Yes | No | 4
Ritvanen 2007 147 | Not clear | Not clear | Yes | No | No | Yes | Not clear | Not clear | Yes | Yes | No | Yes | Not clear | 5
Timm 1994 148 | Not clear | Not clear | Yes | No | No | Yes | No | Not clear | Yes | Yes | Not clear | Yes | No | 4
Wreje 1992 149 | Not clear | Not clear | Not clear | Not clear | No | Not clear | Yes | Yes | Yes | Yes | Not clear | No | Not clear | 4
Zaproudina 2009 150 | Not clear | Not clear | Yes | No | No | Yes | Not clear | Yes | Yes | Yes | Not clear | Not clear | Not clear | 5

Table 1.4 Low Back Pain - Massage

Study ID | Q1. Randomization Adequate? | Q2. Treatment Allocation Concealed? | Q3. Groups similar at baseline re: prognostic indicators | Q4. Patient blinded to the intervention? | Q5. Care provider blinded to the intervention? | Q6. Outcome assessor blinded to the intervention? | Q7. Co-interventions avoided or similar? | Q8. Compliance acceptable in all groups | Q9. Dropout rate described and acceptable? | Q10. Timing of the outcome assessment in all groups similar? | Q11. Analysis includes an intention-to-treat analysis? | Q12. Reports of the study free of suggestion of selective outcome reporting? | Q13. Is this study free of any other bias? | Total “Yes”
Chatchawan 2005 151 | Yes | Not clear | Yes | Not clear | No | Not clear | Not clear | Yes | Yes | Yes | Yes | Not clear | Not clear | 6
Cherkin 2001 10 | Yes | No | Yes | No | No | No | Not clear | Yes | Yes | Yes | Yes | No | Not clear | 6
Farasyn 2006 152 | Not clear | Not clear | Yes | No | No | Not clear | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | 7
Field 2007 153 | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Not clear | 2
Franke 2000 154 | Yes | Not clear | Yes | No | Not clear | Not clear | Yes | Yes | Yes | Yes | No | Yes | Yes | 8
Geisser 2005 155 | Don’t know | Don’t know | Yes | Don’t know | No | Yes | Don’t Know | No | No | Don’t know | Don’t know | Yes | Don’t Know
Hernandez-Reif 2001 156 | Not clear | Not clear | Not clear | No | No | Not clear | Not clear | Not clear | Not clear | Yes | No | Yes | No | 2
Hoehler 1981 115 | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Not clear | 3
Hsieh 2004 157 | Yes | No | Yes | Not clear | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | 9
Hsieh 2006 158 | Yes | Yes | Yes | No | No | Yes | Not clear | Yes | Yes | Yes | Yes | Yes | Not clear | 9
Konrad 1992 159 | Not clear | Not clear | Yes | No | No | Yes | Yes | Yes | Yes | Yes | No | No | Not clear | 6
Li 2006 143 | Yes | Yes | Yes | Yes | Not clear | Yes | Yes | Not clear | Yes | Yes | Yes | Not clear | Yes | 10
Little 2008 160 | Yes | Yes | Yes | Not clear | Not clear | Yes | Not clear | Yes | Yes | Yes | Not clear | Yes | Not clear | 8
Mackawan 2007 145 | Not clear | Not clear | No | No | No | Not clear | Not clear | Yes | Yes | Yes | Yes | Yes | Not clear | 5
Poole 2007 161 | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Yes | Yes | Yes | Not clear | 5
Pope 1994 124 | Not clear | Yes | Yes | No | No | Yes | Not clear | No | Not clear | Yes | No | Yes | Not clear | 5
Preyde 2000 162 | Yes | Not clear | Yes | No | No | Yes | Not clear | Not clear | Yes | Yes | No | Yes | No | 6
Quinn 2008 163 | Yes | No | Yes | Yes | No | Yes | Not clear | Yes | Yes | Yes | Yes | Yes | Not clear | 9
Yip 2004 164 | No | No | Yes | Not clear | No | No | Yes | Yes | Yes | Yes | Not clear | No | Not clear | 5
Zhang 2004 165 | Yes | Not clear | Yes | Yes | Not clear | Not clear | Yes | Yes | No | Not clear | Yes | Not clear | Not clear | 6

Table 1.5 Low Back Pain - Manual Treatment

Study ID | Q1. Randomization Adequate? | Q2. Treatment Allocation Concealed? | Q3. Groups similar at baseline re: prognostic indicators | Q4. Patient blinded to the intervention? | Q5. Care provider blinded to the intervention? | Q6. Outcome assessor blinded to the intervention? | Q7. Co-interventions avoided or similar? | Q8. Compliance acceptable in all groups | Q9. Dropout rate described and acceptable? | Q10. Timing of the outcome assessment in all groups similar? | Q11. Analysis includes an intention-to-treat analysis? | Q12. Reports of the study free of suggestion of selective outcome reporting? | Q13. Is this study free of any other bias? | Total “Yes”
Aure 2003 166 | Yes | Yes | Yes | No | No | Not clear | Yes | Yes | Yes | Yes | Yes | No | Not clear | 8
Farrell 1982 167 | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Yes | Not clear | 4
Ferreira 2007 168 | Yes | Yes | Yes | No | No | Yes | Not clear | Not clear | Yes | Yes | No | Yes | Not clear | 7
Hancock 2007 169 | Yes | Yes | Yes | Yes | No | Yes | Not clear | Not clear | Yes | Yes | Not clear | Yes | Yes | 9
Hurley 2004 170 | Yes | No | Yes | No | No | Yes | Yes | No | No | Yes | Yes | No | Not clear | 6
Hurwitz 2006 171 | Yes | Yes | Yes | No | No | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Yes | Not clear | 6
Koes 1992 172 | Yes | Not clear | Yes | No | No | Yes | Not clear | No | Yes | Yes | Not clear | No | No | 5
MacDonald 1990 173 | Not clear | Not clear | Yes | No | No | Not clear | Yes | Yes | Yes | Yes | Not clear | No | Not clear | 5
Meade 1991 174 | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Yes | Yes | Yes | Not clear | 5
Sims-Williams 1979 175 | Not clear | Not clear | No | Yes | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Not clear | 4

Table 1.6 Low Back Pain — Flexion Distraction

Study ID | Q1. Randomization Adequate? | Q2. Treatment Allocation Concealed? | Q3. Groups similar at baseline re: prognostic indicators | Q4. Patient blinded to the intervention? | Q5. Care provider blinded to the intervention? | Q6. Outcome assessor blinded to the intervention? | Q7. Co-interventions avoided or similar? | Q8. Compliance acceptable in all groups | Q9. Dropout rate described and acceptable? | Q10. Timing of the outcome assessment in all groups similar? | Q11. Analysis includes an intention-to-treat analysis? | Q12. Reports of the study free of suggestion of selective outcome reporting? | Q13. Is this study free of any other bias? | Total “Yes”
Beyerman 2006 176 | Not clear | Not clear | Yes | No | No | Not clear | Not clear | Not clear | Yes | Yes | No | Yes | Not clear | 4
Cambron 2006 177 | Not clear | Not clear | No | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Yes | No | Yes | Not clear | 3
Hawk 1999 178 | Not clear | Yes | Not clear | Yes | Not clear | Not clear | Not clear | Not clear | Yes | Yes | Not clear | No | Not clear | 4
Hawk 2005 179 | Yes | Yes | Yes | Yes | No | Not clear | Not clear | Not clear | Yes | Yes | Yes | Yes | Not clear | 8

Table 2.1 Neck Pain - Acupuncture

Study ID | Q1. Randomization Adequate? | Q2. Treatment Allocation Concealed? | Q3. Groups similar at baseline re: prognostic indicators | Q4. Patient blinded to the intervention? | Q5. Care provider blinded to the intervention? | Q6. Outcome assessor blinded to the intervention? | Q7. Co-interventions avoided or similar? | Q8. Compliance acceptable in all groups | Q9. Dropout rate described and acceptable? | Q10. Timing of the outcome assessment in all groups similar? | Q11. Analysis includes an intention-to-treat analysis? | Q12. Reports of the study free of suggestion of selective outcome reporting? | Q13. Is this study free of any other bias? | Total “Yes”
Abernethy 2008 180 | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | 0
Aigner 1999 181 | Yes | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | Not clear | Yes | No | Yes | Yes | 6
Allison 2002 182 | Not clear | Not clear | Yes | No | No | Yes | Not clear | Not clear | Not clear | Yes | Yes | Yes | Not clear | 5
Bin 2007 183 | Not clear | Not clear | Yes | Not clear | Not clear | Yes | Yes | No | No | Not clear | Not clear | Yes | Not clear | 5
Birch 1998 184 | Not clear | Not clear | Yes | No | No | Not clear | Not clear | No | No | Yes | Not clear | No | Not clear | 2
Ceccherelli 2006 185 | Yes | Not clear | Yes | No | No | Yes | Not clear | Not clear | Yes | Yes | Not clear | Yes | Not clear | 6
Chu 1997 186 | Not clear | No | No | Not clear | Not clear | Not clear | Not clear | No | No | Yes | Not clear | No | Not clear | 1
Coan 1981 187 | Yes | Yes | No | Not clear | Not clear | Not clear | Not clear | Yes | Yes | No | Not clear | No | Not clear | 4
David 1998 188 | Not clear | No | Yes | No | No | Not clear | Not clear | Yes | Yes | Yes | Not clear | No | Not clear | 4
Edwards 2003 189 | Not clear | Not clear | Yes | No | No | Yes | Not clear | Not clear | Yes | Yes | Yes | Yes | Not clear | 6
Fu 2005 190 | Not clear | No | Yes | No | Not clear | Not clear | Yes | Not clear | No | Yes | No | Not clear | No | 3
Fu 2007 191 | Not clear | Not clear | Yes | No | No | Yes | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Not clear | 4
Ga 2007 192 | Not clear | Not clear | Yes | No | Not clear | Yes | Not clear | Not clear | Yes | Yes | Not clear | Yes | Not clear | 4
Gallacchi 1983 193 | Not clear | Not clear | Yes | No | Not clear | Not clear | Not clear | Not clear | Yes | Yes | No | Yes | Yes | 5
Giles 1999 21 | Not clear | Not clear | No | No | No | Not clear | Not clear | No | No | Not clear | No | Yes | No | 1
Giles 2003 22 | Yes | Yes | No | No | No | Yes | No | No | No | Yes | Yes | No | Not clear | 5
Hoehler 1981 115 | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Not clear | 3
Huang 2008 194 | Yes | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 4
Ilbuldu 2004 195 | Not clear | Not clear | Yes | No | No | Yes | Yes | Not clear | Not clear | Yes | Not clear | Yes | Not clear | 5
Irnich 2001 196 | Not clear | Not clear | No | No | Not clear | Not clear | Not clear | Yes | Yes | Yes | Yes | No | Not clear | 4
Itoh 2007 197 | Not clear | Not clear | Yes | Yes | No | Yes | Not clear | Not clear | Yes | Yes | No | Yes | Not clear | 6
Jia 2007 198 | Yes | Not clear | Yes | Yes | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 5
Li 2004 199 | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Yes | Not clear | Not clear | 4
Li 2006 200 | Yes | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Yes | Yes | Not clear | Not clear | 5
Liang 2009 201 | Yes | Yes | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Yes | Yes | Not clear | Yes | Not clear | 6
Lin 2004 202 | Not clear | Not clear | Yes | No | No | Not clear | Not clear | Not clear | No | Yes | No | Yes | Not clear | 3
Lu 2006 203 | No | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 3
Lundeberg 1991 204 | Not clear | Not clear | Not clear | Not clear | No | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | 1
Nabeta 2002 205 | Not clear | Not clear | Not clear | Yes | No | Not clear | Not clear | Yes | Yes | Yes | Yes | No | Not clear | 5
Petrie 1983 206 | Not clear | Not clear | Yes | No | No | Not clear | No | Yes | Yes | Yes | Yes | Yes | Not clear | 6
Petrie 1986 207 | Not clear | Not clear | No | Yes | No | Not clear | Not clear | Yes | Yes | Yes | Not clear | Yes | Not clear | 5
Salter 2006 208 | Yes | Not clear | Yes | No | No | Not clear | Not clear | Not clear | Yes | Yes | Yes | Yes | Not clear | 6
Sator-Katzenschlager 2003 209 | No | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Yes | Not clear | No | Not clear | 4
Seidel 2002 210 | Yes | Not clear | Yes | Yes | Yes | Not clear | Yes | Yes | Yes | Yes | No | Yes | Yes | 10
Shang 2002 211 | Yes | Yes | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Yes | Yes | Not clear | Yes | Not clear | 6
Vas 2006 212 | Not clear | Yes | Yes | No | No | Yes | Not clear | Not clear | Yes | Yes | Yes | Yes | Not clear | 7
Venancio 2008 213 | Not clear | Not clear | No | No | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | Not clear | Yes | Not clear | 2
Wang 2007 214 | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 3
Wang 2007 215 | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Not clear | Not clear | No | Yes | Not clear | Not clear | Not clear | 2
Wang 2008 216 | Yes | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 4
White 2000 217 | Not clear | Not clear | Not clear | No | No | Yes | Not clear | Not clear | Yes | Yes | Yes | Yes | Not clear | 5
White 2004 218 | Yes | Yes | Yes | Yes | No | Not clear | Yes | Yes | Yes | Yes | Yes | No | Not clear | 9
Witt 2006 219 | Yes | Yes | Yes | No | No | Not clear | Not clear | Not clear | Yes | Yes | Yes | Yes | Not clear | 7
Yang 2009 220 | Yes | Yes | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Yes | Yes | Not clear | Yes | Not clear | 6
Zeng 2005 221 | Not clear | Not clear | Yes | Yes | Not clear | Not clear | Yes | Not clear | No | Yes | Yes | Not clear | Not clear | 5
Zhang 2003 222 | Yes | Yes | Yes | Not clear | Not clear | Not clear | Yes | Yes | No | Yes | No | Not clear | No | 6
Zhang 2005 223 | Not clear | Not clear | Not clear | No | No | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | 0
Zhao 2004 224 | Yes | Not clear | Yes | No | Not clear | Not clear | Not clear | Not clear | No | Yes | Not clear | Not clear | Not clear | 3
Zhu 2002 225 | Not clear | Yes | Yes | No | No | Yes | Not clear | Yes | Yes | Yes | Not clear | Yes | Not clear | 7
Zhu 2006 226 | Yes | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Not clear | Not clear | Not clear | 4
Zhuang 2004 227 | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Not clear | No | Yes | Yes | Not clear | Not clear | 4

Table 2.2 Neck Pain - Manipulation

Study ID | Q1. Randomization Adequate? | Q2. Treatment Allocation Concealed? | Q3. Groups similar at baseline re: prognostic indicators | Q4. Patient blinded to the intervention? | Q5. Care provider blinded to the intervention? | Q6. Outcome assessor blinded to the intervention? | Q7. Co-interventions avoided or similar? | Q8. Compliance acceptable in all groups | Q9. Dropout rate described and acceptable? | Q10. Timing of the outcome assessment in all groups similar? | Q11. Analysis includes an intention-to-treat analysis? | Q12. Reports of the study free of suggestion of selective outcome reporting? | Q13. Is this study free of any other bias? | Total “Yes”
Bischoff 2003 228 | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | Not clear | Not clear | Not clear | 1
Buchmann 2005 229 | Yes | Not clear | Not clear | No | No | Yes | Yes | Yes | Yes | Yes | Not clear | Yes | Not clear | 7
Cassidy 1992 230 | Not clear | Not clear | Yes | No | No | Not clear | Not clear | Yes | Yes | Yes | Yes | Yes | Not clear | 6
Chen 2007 231 | Yes | Not clear | Yes | Not clear | Not clear | Not clear | Yes | Yes | Yes | Yes | Not clear | Yes | Not clear | 7
Cilliers 1998 232 | Not clear | Not clear | Yes | No | No | Not clear | Yes | Not clear | Not clear | Yes | Not clear | No | Not clear | 3
Cleland 2004 233 | Not clear | Not clear | Yes | No | No | Yes | Not clear | Not clear | Not clear | Not clear | Not clear | No | Not clear | 2
Cleland 2005 234 | Yes | Yes | Yes | No | No | Not clear | Not clear | Not clear | Yes | Yes | Yes | Yes | Not clear | 7
Cleland 2007 235 | Yes | Yes | Yes | No | No | Not clear | Not clear | Not clear | Yes | Yes | Yes | Yes | Not clear | 7
Egwu 2008 236 | No | Not clear | Yes | Not clear | No | No | Yes | Yes | Yes | Yes | No | Yes | Not clear | 6
Fernandez-de-Las-Penas 2004 237 | Yes | Not clear | Yes | Not clear | No | Not clear | Not clear | Yes | Yes | Yes | Yes | Not clear | Not clear | 6
Giles 1999 21 | Not clear | Not clear | No | No | No | Not clear | Not clear | No | No | Not clear | No | Yes | No | 1
Giles 2003 22 | Yes | Yes | No | No | No | Yes | No | No | No | Yes | Yes | No | Not clear | 5
Giles 2003 22 | Yes | Yes | No | No | No | Yes | No | No | No | Yes | Yes | No | Not clear | 5
Gonzalez-Iglesias 2009 238 | Yes | Yes | Yes | No | No | Yes | Not clear | Yes | Yes | Yes | Yes | Yes | Not clear | 9
Haas 2003 239 | No | No | Yes | No | Yes | Not clear | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | 8
Haas 2004 240 | Not clear | Yes | Yes | No | No | Not clear | Not clear | Yes | Yes | Yes | Yes | Yes | Not clear | 7
Hurwitz 2002 241 | Not clear | Yes | Yes | No | No | Not clear | Not clear | Not clear | Not clear | Yes | No | Yes | Not clear | 4
Krauss 2008 242 | Yes | Not clear | Yes | No | No | Yes | Yes | Not clear | Yes | Yes | Yes | Yes | Yes | 9
Martinez-Segura 2006 243 | Yes | Yes | Yes | No | No | Yes | Not clear | Not clear | No | Yes | Not clear | Yes | No | 6
Metcalfe 2006 244 | Not clear | Not clear | No | No | No | Not clear | Not clear | Yes | Yes | Yes | Not clear | Yes | Not clear | 4
Nilsson 1997 245 | Yes | No | Yes | Yes | No | Yes | No | Yes | Yes | Yes | Not clear | Not clear | Not clear | 7
Parkin-Smith 1998 246 | Yes | Yes | Yes | No | No | No | Yes | Not clear | Not clear | Yes | Not clear | Yes | Not clear | 6
Pikula 1999 247 | Yes | Not clear | Not clear | No | No | No | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Yes | 4
Sloop 1982 248 | Not clear | Not clear | Yes | Yes | No | Yes | No | Not clear | Yes | Yes | Not clear | No | Not clear | 5
Strunk 2008 249 | Yes | Yes | Not clear | No | No | Not clear | Yes | Yes | Yes | Yes | Not clear | Not clear | No | 6
van Schalkwyk 2000 250 | No | No | Not clear | No | No | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | No | 1
Vernon 1990 251 | Not clear | No | No | Not clear | No | Yes | Not clear | Yes | Yes | Yes | Yes | Yes | Not clear | 6
Whittingham 2001 252 | Yes | Yes | Yes | Yes | No | Not clear | Not clear | Yes | Yes | Yes | Not clear | Yes | Not clear | 8
Yurkiw 1996 253 | Yes | Not clear | Not clear | No | No | Yes | Not clear | Yes | Yes | Yes | Yes | Yes | Not clear | 7

Table 2.3 Neck Pain - Mobilization

Study ID | Q1. Randomization Adequate? | Q2. Treatment Allocation Concealed? | Q3. Groups similar at baseline re: prognostic indicators | Q4. Patient blinded to the intervention? | Q5. Care provider blinded to the intervention? | Q6. Outcome assessor blinded to the intervention? | Q7. Co-interventions avoided or similar? | Q8. Compliance acceptable in all groups | Q9. Dropout rate described and acceptable? | Q10. Timing of the outcome assessment in all groups similar? | Q11. Analysis includes an intention-to-treat analysis? | Q12. Reports of the study free of suggestion of selective outcome reporting? | Q13. Is this study free of any other bias? | Total “Yes”
Brodin 1983 254 | Not clear | Not clear | Yes | No | No | Not clear | Not clear | Not clear | Yes | Yes | Not clear | No | Not clear | 3
Buchmann 2005 229 | Yes | Not clear | Not clear | No | No | Yes | Yes | Yes | Yes | Yes | Not clear | Yes | Not clear | 7
Cassidy 1992 230 | Not clear | Not clear | Yes | No | No | Not clear | Not clear | Yes | Yes | Yes | Yes | Yes | Not clear | 6
Coppieters 2003 255 | Not clear | Yes | Yes | No | No | Yes | Not clear | Not clear | Not clear | Yes | Not clear | Yes | Not clear | 5
Hemmila 2005 256 | Not clear | Not clear | No | No | No | Yes | Not clear | Not clear | Yes | Yes | Yes | Yes | Not clear | 5
Hoving 2006 257 | Yes | Yes | Not clear | No | No | Yes | No | Not clear | Yes | Yes | Yes | Yes | Not clear | 7
Hurwitz 2002 241 | Not clear | Yes | Yes | No | No | Not clear | Not clear | Not clear | Not clear | Yes | No | Yes | Not clear | 4
Kanlayanaphotporn 2009 258 | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | Yes | Yes | Yes | Yes | Yes | Not clear | 11
Martinez-Segura 2006 243 | Yes | Yes | Yes | No | No | Yes | Not clear | Not clear | No | Yes | Not clear | Yes | No | 6
Martinez-Segura 2006 243 | Yes | Yes | Yes | No | No | Yes | Not clear | Not clear | No | Yes | Not clear | Yes | No | 6
Sterling 2001 259 | Yes | Yes | Not clear | Not clear | Yes | Yes | Not clear | Yes | Yes | Yes | Not clear | No | Not clear | 7
Zaproudina 2007 260 | Not clear | Not clear | Yes | Yes | No | Yes | Not clear | Not clear | Yes | Yes | No | Yes | Not clear | 6

Table 2.4 Neck Pain - Massage

Study ID | Q1. Randomization Adequate? | Q2. Treatment Allocation Concealed? | Q3. Groups similar at baseline re: prognostic indicators | Q4. Patient blinded to the intervention? | Q5. Care provider blinded to the intervention? | Q6. Outcome assessor blinded to the intervention? | Q7. Co-interventions avoided or similar? | Q8. Compliance acceptable in all groups | Q9. Dropout rate described and acceptable? | Q10. Timing of the outcome assessment in all groups similar? | Q11. Analysis includes an intention-to-treat analysis? | Q12. Reports of the study free of suggesti on of selective outcome reporting? | Q13. Is this study free of any other bias? | Total “Yes”
Blikstad 2008 261 | Yes | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Not clear | 10
Cen 2003 262 | Yes | Not clear | No | No | No | Not clear | Not clear | Not clear | Yes | Yes | No | Yes | Not clear | 4
Fernandez-de-Las-Penas 2006 263 | Not clear | Not clear | Yes | No | No | Yes | Not clear | Yes | Yes | Yes | Yes | Yes | Not clear | 7
Gemmell 2008 264 | Yes | Yes | Yes | No | No | Yes | Not clear | Yes | Yes | Yes | Yes | Yes | No | 9
Hanten 1997 265 | Not clear | Not clear | Yes | No | No | Not clear | Not clear | Yes | Yes | Yes | Yes | Yes | Not clear | 6
Irnich 2001 196 | Not clear | Not clear | No | No | Not clear | Not clear | Not clear | Yes | Yes | Yes | Yes | No | Not clear | 4
Lin 2004 202 | Not clear | Not clear | Yes | No | No | Not clear | Not clear | Not clear | No | Yes | No | Yes | Not clear | 3
Meseguer 2006 266 | Yes | Not clear | Yes | No | No | Yes | Not clear | Not clear | Yes | Yes | No | Yes | Not clear | 6
Sherman 2009 267 | Yes | Yes | Not clear | No | No | Yes | Yes | Yes | Yes | Yes | Yes | No | Not clear | 8
Yagci 2004 268 | Not clear | Not clear | No | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Yes | No | Yes | Not clear | 2
Zaproudina 2007 260 | Not clear | Not clear | Yes | Yes | No | Yes | Not clear | Not clear | Yes | Yes | No | Yes | Not clear | 6
Zhang 2005 269 | Not clear | Not clear | Yes | No | No | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | No | Not clear | 1
Zhang 2005 223 | Not clear | Not clear | Not clear | No | No | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | Not clear | 0

Table 3.1 Headache - Acupuncture

Study ID | Q1. Randomization Adequate? | Q2. Treatment Allocation Concealed? | Q3. Groups similar at baseline re: prognostic indicators | Q4. Patient blinded to the intervention? | Q5. Care provider blinded to the intervention? | Q6. Outcome assessor blinded to the intervention? | Q7. Co-interventions avoided or similar? | Q8. Compliance acceptable in all groups | Q9. Dropout rate described and acceptable? | Q10. Timing of the outcome assessment in all groups similar? | Q11. Analysis includes an intention-to-treat analysis? | Q12. Reports of the study free of suggestion of selective outcome reporting? | Q13. Is this study free of any other bias? | Total “Yes”
Carlsson 1990 270 | Not clear | Not clear | Yes | No | No | Yes | Yes | Yes | Yes | No | Not clear | Yes | Not clear | 6
Venancio 2008 213 | Not clear | Not clear | No | No | Not clear | Not clear | Not clear | Not clear | Yes | Not clear | Not clear | Yes | Not clear | 2

Table 3.2 Headache - Manipulation

Study ID | Q1. Randomization Adequate? | Q2. Treatment Allocation Concealed? | Q3. Groups similar at baseline re: prognostic indicators | Q4. Patient blinded to the intervention? | Q5. Care provider blinded to the intervention? | Q6. Outcome assessor blinded to the intervention? | Q7. Co-interventions avoided or similar? | Q8. Compliance acceptable in all groups | Q9. Dropout rate described and acceptable? | Q10. Timing of the outcome assessment in all groups similar? | Q11. Analysis includes an intention-to-treat analysis? | Q12. Reports of the study free of suggestion of selective outcome reporting? | Q13. Is this study free of any other bias? | Total “Yes”
Nilsson 1997 245 | Yes | No | Yes | Yes | No | Yes | No | Yes | Yes | Yes | Not clear | Not clear | Not clear | 7
Whittingham 2001 252 | Yes | Yes | Yes | Yes | No | Not clear | Not clear | Yes | Yes | Yes | Not clear | Yes | Not clear | 8

Table 4.1 Thoracic Pain

Study ID | Q1. Randomization Adequate? | Q2. Treatment Allocation Concealed? | Q3. Groups similar at baseline re: prognostic indicators | Q4. Patient blinded to the intervention? | Q5. Care provider blinded to the intervention? | Q6. Outcome assessor blinded to the intervention? | Q7. Co-interventions avoided or similar? | Q8. Compliance acceptable in all groups | Q9. Dropout rate described and acceptable? | Q10. Timing of the outcome assessment in all groups similar? | Q11. Analysis includes an intention-to-treat analysis? | Q12. Reports of the study free of suggestion of selective outcome reporting? | Q13. Is this study free of any other bias? | Total “Yes”
Schiller 2001 271 | Not clear | Not clear | Not clear | Not clear | No | No | Yes | Not clear | Not clear | Yes | Not clear | No | Not clear | 2

Table 5.1 Methodological quality of economic evaluations on back pain using the CHEC-list

| Hollinghurst et al160, 272 | Kominski et al171, 273-280 | Seferlis et al281, 282 | Niemisto et al283 | Ratcliffe et al74, 284-292 | Witt et al 2006^81, 293, 294^ | UK BEAM Trial Team132, 295, 296
Study population described | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Competing alternatives described | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Research question posed in answerable form | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Appropriate study design | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Appropriate time horizon | Yes | Yes | Yes | Yes | Yes | No | Yes
Appropriate perspective | Yes | No | No | Yes | Yes | Yes | No
All costs identified | Yes | No | Yes | Yes | Yes | No | Yes
All costs measured appropriately | Yes | Yes | No | Yes | Yes | Not clear | Yes
Costs valued appropriately | Yes | Yes | No | Yes | Yes | No | Yes
All outcomes identified | Yes | NA | NA | Yes | Yes | Yes | Yes
All outcomes measured appropriately | Yes | NA | NA | Yes | Yes | Yes | Yes
Outcomes valued appropriately | Yes | NA | NA | Yes | Yes | Yes | Yes
Incremental analysis of costs and outcomes performed | Yes | NA | NA | Yes | Yes | Yes | Yes
Discounting | NA | No | NA | No | Yes | NA | NA
Sensitivity analysis | Yes | No | No | No | Yes | No | Yes
Conclusions follow from the data reported | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Generalisability discussed | No | Yes | No | Yes | Yes | Yes | Yes
No potential conflict of interest | Yes | Yes | No | Yes | Yes | Yes | Yes
Ethical and distributional issues discussed appropriately | Yes | Yes | No | No | Yes | Yes | Yes

Table 5.2 Methodological quality of economic evaluations on neck pain using the CHEC-list

| Korthals-de Bos et al297 | Lewis et al298, 299 | Willich et al219, 300
Study population described | Yes | Yes | No
Competing alternatives described | Yes | Yes | No
Research question posed in answerable form | Yes | Yes | Yes
Appropriate study design | Yes | Yes | Yes
Appropriate time horizon | Yes | Yes | No
Appropriate perspective | Yes | Yes | Yes
All costs identified | Yes | Yes | Yes
All costs measured appropriately | Yes | Yes | Yes
Costs valued appropriately | Yes | Yes | No
All outcomes identified | Yes | Yes | Yes
All outcomes measured appropriately | Yes | Yes | Yes
Outcomes valued appropriately | Yes | Yes | Yes
Incremental analysis of costs and outcomes performed | Yes | Yes | Yes
Discounting | NA | NA | Yes
Sensitivity analysis | No | No | Yes
Conclusions follow from the data reported | Yes | Yes | Yes
Generalisability discussed | No | No | No
No potential conflict of interest | Yes | Yes | Yes
Ethical and distributional issues discussed appropriately | No | No | No

Table 6.1 Quality Assessment on Observational Studies

Item | Cassidy 2008^301^ | Kohlbeck 2005^302^ | Cook 2008^303^ | Rothwell 2001^304^ | Smith 2003^305^
Reporting
Is the hypothesis/aim/objective of the study clearly described? | Yes | Yes | Yes | Yes | Yes
Are the main outcomes to be measured clearly described in the Introduction or Methods section? | Yes | Yes | Yes | Yes | No
Are the characteristics of the patients included in the study clearly described? | Yes | Yes | Yes | No | Yes
Are the interventions of interest clearly described? | Yes | Yes | Yes | Yes | Unable to determine
Are the distributions of principal cofounders in each group of subjects to be compared clearly described? | No | No | No | Unable to determine | No
Are the main findings of the study clearly described? | Yes | Yes | Yes | Yes | Yes
Does the study provide estimates of the random variability in the data for the main outcome? | No | No | Unable to determine | Yes | No
Have all the important adverse events that may be a consequence of the intervention been reported? | Yes | Yes | Unable to determine | No | Yes
Have the characteristics of patients lost to follow-ups been described? | No | No | No | Unable to determine | No
Have actual probability values been reported (e.g. 0.035 rather than <0.05) for the main outcomes except where the probability value is less than 0.001? | No | No | Unable to determine | Unable to determine | No
External validity
Were the subjects asked to participate in the study representative of the entire population from which they were recruited? | Unable to determine | Yes | Unable to determine | Unable to determine | Yes
Were those subjects who were prepared to participate representative of the entire population from which they were recruited? | Unable to determine | Unable to determine | Unable to determine | Unable to determine | Unable to determine
Were the staff, places and facilities where the patients were treated, representative of the treatment the majority of patients receive? | Unable to determine | Unable to determine | Unable to determine | Unable to determine | Unable to determine
Internal validity - bias
Was an attempt made to blind study subjects to the intervention they have received? | Unable to determine | No | Unable to determine | No | Unable to determine
Was an attempt made to blind those measuring the main outcomes of the intervention? | No | No | Unable to determine | No | Yes
If any of the results of the study were based on “data dredging”, was this made clear? | No | Unable to determine | Unable to determine | Unable to determine | Unable to determine
In trials and cohort studies, do the analyses adjust for different lengths of follow-up of patients, or in case-control studies, is the time period between intervention and outcome the same for cases and control? | Unable to determine | Yes | Unable to determine | Yes | Yes
Were the statistical tests used to assess the main outcomes appropriate? | Unable to determine | Unable to determine | Yes | Unable to determine | Unable to determine
Was compliance with the intervention/s reliable? | Unable to determine | Unable to determine | Unable to determine | Unable to determine | Yes
Were the main outcome measures used accurate (valid and reliable)? | Unable to determine | Yes | Unable to determine | Unable to determine | Unable to determine
Internal validity – confounding (selection bias)
Were the patients in different intervention groups (trials and cohort studies) or were the cases and controls (case-control studies) recruited from the same population? | Yes | Yes | Unable to determine | Yes | Yes
Were study subjects in different intervention groups (trials and cohort studies) or were the cases and controls (case-control studies) recruited over the same period of time? | No | Yes | Unable to determine | Yes | Yes
Were study subjects randomized to intervention groups? | No | No | No | No | No
Was the randomized intervention assignment concealed from both patients and health care staff until recruitment was complete and irrevocable? | No | No | No | No | No
Was there adequate adjustment for confounding in the analyses from which the main findings were drawn? | Yes | Unable to determine | Unable to determine | Unable to determine | Unable to determine
Were loses of patients to follow-up taken into account? | No | Unable to determine | Unable to determine | No | Unable to determine
Power
Did the study have sufficient power to detect a clinically important effect where the probability value for a difference being due to chance is less than 5%? | Unable to determine | Yes | Unable to determine | Unable to determine | Unable to determine
Total Number of Yes | 8 | 12 | 6 | 8 | 10

Table 7.1 Methodological quality of RCTs by CAM treatment type (LBP)

Selected Item of the Cochrane Risk of Bias Tool | Acupuncture (n=104) | Spinal Manipulation (n=28) | Spinal mobilization (n=18) | Spinal Manipulation+ Spinal mobilization (n=9) | Massage (n=20)
Appropriate method of randomization | 44 (43.1) | 6 (18.2) | 6 (37.5) | 6 (66.7) | 10 (50.0)
Inappropriate method of randomization | 10 (9.8) | 4 (12.1) | 1 (6.3) | 0 | 1 (5.0)
Appropriate concealment of treatment allocation | 20 (19.6) | 3 (9.1) | 3 (18.8) | 4 (44.4) | 4 (20.0)
Inappropriate concealment of treatment allocation | 11 (10.8) | 7 (21.2) | 2 (12.5) | 1 (11.1) | 3 (15.0)
Dissimilarity of baseline prognostic indicators | 8 (7.8) | 3 (9.1) | 1 (6.3) | 1 (11.0) | 1 (5.0)
Appropriate outcome assessor blinding | 29 (28.4) | 15 (45.5) | 10 (62.5) | 5 (55.6) | 4 (40.0)
Inappropriate outcome assessor blinding | 10 (9.8) | 2 (6.1) | 0 | 0 | 2 (10.0)
Imbalance in use of co-interventions between groups | 5 (4.9) | 1 (3.0) | 2 (12.5) | 0 | 0
Described and acceptable drop out rates^1^ | 47 (46.1) | 12 (36.4) | 10 (62.5) | 7 (77.8) | 14 (70.0)
Unacceptable drop out rates | 45 (44.1) | 6 (18.2) | 2 (12.5) | 1 (11.1) | 2 (10.0)
Similarity of timing in assessment of outcomes between groups | 92 (90.2) | 27 (81.8) | 15 (93.8) | 8 (88.9) | 19 (95.0)
Reporting of intention-to-treat analysis | 30 (29.4) | 10 (30.3) | 5 (31.3) | 4 (44.4) | 10 (50.0)
Absence of selected outcome reporting | 39 (38.2) | 17 (51.5) | 10 (62.5) | 5 (55.6) | 13 (65.0)
Selected outcome reporting bias | 17 (16.7) | 10 (30.3) | 2 (12.5) | 4 (44.4) | 4 (20.0)
Total Score of Risk of Bias (max 13) Median (Inter Quartile Range) | 4 (1, 3) | 2 (3, 6) | 7 (4, 7) | 8 (3, 6) | 6 (5, 8)

^1^ Item number # 9 of the Cochrane risk of bias tool: the number of participants who were included in the study but did not complete the observation period or were not included in the analysis must be described and reasons given. If the percentage of withdrawals and drop-outs does not exceed 20% for short-term follow-up and 30% for long-term follow-up and does not lead to substantial bias a “yes” is scored. (N.B. these percentages are arbitrary, not supported by literature).

Table 7.2 Methodological quality of RCTs by CAM treatment type (NP)

Item | Acupuncture (n=54) | Spinal Manipulation (n=30) | Spinal mobilization (n=11) | Spinal Manipulation+ Spinal mobilization (n=2) | Massage (n= 16)
Appropriate method of randomization | 14 (26.4) | 15 (51.7) | 4 (44.4) | | 6 (37.5)
Inappropriate method of randomization | 4 (7.5) | 2 (6.9) | 1 (11.1) | | 0
Appropriate concealment of treatment allocation | 8 (15.1) | 10 (34.5) | 5 (55.6) | | 3 (18.8)
Inappropriate concealment of treatment allocation | 2 (3.8) | 4 (13.8) | 1 (11.1) | | 0
Dissimilarity of baseline prognostic indicators | 6 (11.3) | 4 (13.8) | 0 | | 5 (31.3)
Appropriate outcome assessor blinding | 14 (26.4) | 10 (34.5) | 5 (55.6) | | 7 (43.8)
Inappropriate outcome assessor blinding | 0 | 2 (6.9) | 5 (55.6) | | 1 (6.3)
Imbalance in use of co-interventions between groups | 1 (1.9) | 3 (10.3) | 0 | | 0
Described and acceptable drop out rates^2^ | 27 (50.9) | 19 (65.5) | 5 (55.6) | | 10 (62.5)
Unacceptable drop out rates | 14 (26.4) | 3 (10.3) | 1 (11.1) | | 1 (6.3)
Similarity of timing in assessment of outcomes between groups | 41 (77.4) | 24 (82.8) | 9 (100.0) | | 14 (87.5)
Reporting of intention-to-treat analysis | 13 (24.5) | 12 (41.4) | 2 (22.2) | | 7 (43.8)
Absence of selected outcome reporting | 26 (49.1) | 20 (69.0) | 6 (66.7) | | 11 (68.8)
Selected outcome reporting bias | 8 (15.1) | 5 (17.2) | 3 (33.3) | | 4 (25.0)
Total Score of Risk of Bias (max 13) Median (Inter Quartile Range) | 4 (3, 6) | 3 (4, 7) | 3 (5, 7) | Only two trials (NA) | 5 (3, 6)

^2^ Item number # 9 of the Cochrane risk of bias tool: the number of participants who were included in the study but did not complete the observation period or were not included in the analysis must be described and reasons given. If the percentage of withdrawals and drop-outs does not exceed 20% for short-term follow-up and 30% for long-term follow-up and does not lead to substantial bias a “yes” is scored. (N.B. these percentages are arbitrary, not supported by literature).

## Reference List

1 Araki S, Kawamura O, Mataka T, et al. [Randomized controlled trial comparing the effect of manual acupuncture with sham acupunture ofr acute low back pain]. J Japan Soc Acupunct Moxibustion. 2001;51(3):382.
2 Brinkhaus B, Witt CM, Jena S, et al. Acupuncture in patients with chronic low back pain: a randomized controlled trial. [see comment]. Arch Intern Med. Feb 27. 2006;166(4):450-7. [pmid: 16505266].
3 Cao W, Wang J. Curative effect of acute lumbago with different acupuncture and moxibustion methods. Int J Clin Acupunct. 2001;12(1):21-9.
4 Carlsson CP, Sjolund BH. Acupuncture for chronic low back pain: a randomized placebo-controlled study with long-term follow-up. Clin J Pain. Dec. 2001;17(4):296-305. [pmid: 11783809].
5 Ceccherelli F, Rigoni MT, Gagliardi G, et al. Comparison of superficial and deep acupuncture in the treatment of lumbar myofascial pain: a double-blind randomized controlled study. Clin J Pain. May. 2002;18(3):149-53. [pmid: 12048416].
6 Ceccherelli F, Gagliardi G, Barbagli P, et al. [Correlation between the number of sessions and therapeutical effect in patients suffering from low back pain treated with acupuncture: a randomized controlled blind study]. [Italian]. Minerva Medica. Aug. 4 Suppl 1. 2003;94:39-44. [pmid: 15108610].
7 Chen X. Comparative study on acupuncture needling methods for sciatica: Routine needling vs. Point-to-point penetration and deep puncture. Am J Acupunct. 1998;26(1):37-41.
8 Chen MR, Wang P, Cheng G, et al. [Effect of warming needle moxibustion on pain threshold in the patient of sciatica]. [Chinese]. Zhongguo Zhen Jiu. Dec. 2005;25(12):831-3. [pmid: 16419700].
9 Chen XY. Observations on the efficacy of deep acupuncture of Jiaji points for treating lumbar intervertebral disc protrusion] [Chinese]. Shanghai J Acupunct Moxibustion. 2007;26(3):21-2.
10 Cherkin DC, Eisenberg D, Sherman KJ, et al. Randomized trial comparing traditional Chinese medical acupuncture, therapeutic massage, and self-care education for chronic low back pain. Arch Intern Med. Apr 23. 2001;161(8):1081-8. [pmid: 11322842].
11 Cherkin DC, Sherman KJ, Avins AL, et al. A randomized trial comparing acupuncture, simulated acupuncture, and usual care for chronic low back pain. Arch Intern Med. May 11. 2009;169(9):858-66. [pmid: 19433697].
12 Chu J, Yuen KF, Wang BH, et al. Electrical twitch-obtaining intramuscular stimulation in lower back pain: a pilot study. [see comment]. Am J Phys Med Rehabil. Feb. 2004;83(2):104-11. [pmid: 14758296].
13 Coan RM, Wong G, Ku SL, et al. The acupuncture treatment of low back pain: a randomized controlled study. Am J Chinese Med. 1980;8(1-2):181-9.
14 Cui J, Xiang K, Liang YY. Scalp acupuncture and massage for treatment of prolapse of lumbar intervertebral disc and effects on immune functions] [Chinese]. Chinese Acupunct Moxibustion. 2004;24(7):445-8.
15 Ding YD. [Fly-probing-acupoint manipulation as a main treatment for lumbago] [Chinese]. Shanghai J Acupunct Moxibustion. 1998;17(5):25-6.
16 Ding XIY. [Clinical observations on the treatment of intervertebral disc protrusion with contralateral acupuncture]. Shanghai J Acupunct Moxibustion. 2002;21(4):24.
17 Edelist G, Gross AE, Langer F. Treatment of low back pain with acupuncture. Can Anaesth Soc J. 1976;23(3):303-6. [pmid: 132988].
18 Eisenberg DM, Post DE, Davis RB, et al. Addition of choice of complementary therapies to usual care for acute low back pain: a randomized controlled trial. [see comment]. Spine. Jan 15. 2007;32(2):151-8. [pmid: 17224808].
19 Fu ZH, Chen XY, Lu LJ, et al. Immediate effect of Fu's subcutaneous needling for low back pain. Chin Med J. Jun 5. 2006;119(11):953-6. [pmid: 16780777].
20 Garvey TA, Marks MR, Wiesel SW. A prospective, randomized, double-blind evaluation of trigger-point injection therapy for low-back pain. Spine. Sep. 1989;14(9):962-4. [pmid: 2528826].
21 Giles LG, Muller R. Chronic spinal pain syndromes: a clinical pilot trial comparing acupuncture, a nonsteroidal anti-inflammatory drug, and spinal manipulation. [see comment]. J Manipulative Physiol Ther. Jul. 1999;22(6):376-81. [pmid: 10478769].
22 Giles LG, Muller R. Chronic spinal pain: a randomized clinical trial comparing medication, acupuncture, and spinal manipulation. [see comment]. Spine. Jul 15. 2003;28(14):1490-502. [pmid: 12865832].
23 Grant DJ, Bishop-Miller J, Winchester DM, et al. A randomized comparative trial of acupuncture versus transcutaneous electrical nerve stimulation for chronic back pain in the elderly. Pain. Jul. 1999;82(1):9-13. [pmid: 10422654].
24 Gunn CC, Milbrandt WE, Little AS, et al. Dry needling of muscle motor points for chronic low-back pain: a randomized clinical trial with long-term follow-up. Spine. May. 1980;5(3):279-91. [pmid: 6446774].
25 Guo W, Zhang H-J, Lin W-E. Effect of different acupuncture therapies in improving functional disturbance of waist and limbs in patients with multiple lumbar disc herniation at different stages. [Chinese]. Chinese J Clin Rehab. 2005;9(2):184-5.
26 Haake M, Muller HH, Schade-Brittinger C, et al. German Acupuncture Trials (GERAC) for chronic low back pain: randomized, multicenter, blinded, parallel-group trial with 3 groups. [erratum appears in Arch Intern Med. 2007 Oct 22;167(19):2072]. Arch Intern Med. Sep 24. 2007;167(17):1892-8. [pmid: 17893311].
27 He RY. Clinical observation on treatment of lumbago due to cold-dampness by warm-acupuncture plus Chinese medicine. Chinese Acupunct Moxibustion. 1997;17(5):279-80.
28 He XW, Huang JH, Zeng LY. [Observation on the therapeutic effect of warming needle moxibustion on prolapse of lumbar intervertebral disc]. [Chinese]. Zhongguo Zhen Jiu. Apr. 2007;27(4):264-6. [pmid: 17585670].
29 Hirota S, Itoh K, Katsumi Y. A controlled clinical trial comparing trigger point acupuncture with tender point acupuncture treatments for chronic low back pain: A pilot study on 9 elderly patients. J Japan Soc Acupunct Moxibustion. 2006;(56):67-85.
30 Hodgson L, Fryer G. The effect of manual pressure release on myofascial trigger points in the upper trapezius muscle. Int J Osteopath Med. 2006;9(JUN):33.
31 Hollisaz MT. Use of electroacupuncture for treatment of chronic sciatic pain. Internet J Pain Sypmtom Contr Palliat Care. 2006;(1):7p.
32 Huang G-F, Zhang H-X, Zhang T-F, et al. Time-dependent analgesic effect of electroacupuncture at Jiaji acupoint in patients with lumbar disc herniation and its intervention on related factors of plasma. [Chinese]. Chinese J Clin Rehab. 2006;10(43):1-6.
33 Huang S, Zhan H, Shi Y. Clinical lumbar function-recovering effect of different electroacupuncture points on lumbar intervertebral disc herniation. [Chinese]. Chinese J of Rehab Med. 2006;21(6):497-500.
34 Inoue M, Ktakouji H, Ikeuchi R, et al. [Randomized controlled pilot study comparing acupuncture with sham acupunture for lumbago]. J Japan Soc Acupunct Moxibustion. 2000;50(2):356.
35 Inoue M, Ktakouji H, Ikeuchi R, et al. [Randomized controlled pilot study comparing manual acupuncture with sham acupuncture for lumbago (2nd report)]. J Japan Soc Acupunct Moxibustion. 2001;51(3):412.
36 Inoue M, Kitakoji H, Ishizaki N, et al. Relief of low back pain immediately after acupuncture treatment--a randomised, placebo controlled trial. Acupunct Med. Sep. 2006;24(3):103-8. [pmid: 17013356].
37 Itoh K, Katsumi Y, Kitakoji H. Trigger point acupuncture treatment of chronic low back pain in elderly patients--a blinded RCT. Acupunct Med. Dec. 2004;22(4):170-7. [pmid: 15628774].
38 Itoh K, Katsumi Y, Hirota S, et al. Effects of trigger point acupuncture on chronic low back pain in elderly patients--a sham-controlled randomised trial. Acupunct Med. Mar. 2006;24(1):5-12. [pmid: 16618043].
39 Itoh K, Itoh S, Katsumi Y, et al. A pilot study on using acupuncture and transcutaneous electrical nerve stimulation to treat chronic non-specific low back pain. Complement Ther Clin Pract. Feb. 2009;15(1):22-5. [pmid: 19161950].
40 Jia C, Jiang G-M, Liu D-G. Effect of deep acupuncture at jiaji acupoint and acupoint-injection on lumbar disc herniation and the influence on the levels of interleukins. [Chinese]. Chinese J Clin Rehab. 2004;8(17):3324-6.
41 Kawase Y, Ishigami T, Nakamura H, et al. Acupuncture treatment for lower back pain: Multi-center randomized controlled trial using sham acupuncture as a control. J Japan Soc Acupunct Moxibustion. 2006;(56):140-9.
42 Kennedy S, Baxter GD, Kerr DP, et al. Acupuncture for acute non-specific low back pain: a pilot randomised non-penetrating sham controlled trial. Complement Ther Med. Jun. 2008;16(3):139-46. [pmid: 18534326].
43 Kerr DP, Walsh DM, Baxter D. Acupuncture in the management of chronic low back pain: a blinded randomized controlled trial. Clin J Pain. Nov. 2003;19(6):364-70. [pmid: 14600536].
44 Kittang G, Melvaer T, Baerheim A. [Acupuncture contra antiphlogistics in acute lumbago]. [see comment]. [Norwegian]. Tidsskrift for Den Norske Laegeforening. Apr 20. 2001;121(10):1207-10. [pmid: 11402745].
45 Kurosu Y. Acupuncture and moxibustion for lumbago (II) - Compartative experiment of the therapeutic effectiveness of acupuncture and garlic moxibustion. J Japan Soc Acupunct Moxibustion. 1979;28(2):31-4.
46 Kwon Y, Lee S, Lee C, et al. The short-term efficacy of acupuncture for chronic low back pain: randomized sham controlled trial. J Orient Rehab Med. 2007;17(2):123-32.
47 Lai YZ, Zhuang LX, Zhuang ZJ, et al. [Clinical observations on needling xi-cleft points as a main treatment for the acute stage of lumbar intervertebral disc protrusion]. Shanghai J Acupunct Moxibustion. 2004;23(9):22-4.
48 Lee J-W, Kim D-I. A randomized controlled trial to verify effects of Kuesu Point on low back pain and accompanied sciatica. Korean J Oriental Med. 2007;28(4):86-94.
49 Lehmann TR, Russell DW, Spratt KF. The impact of patients with nonorganic physical findings on a controlled trial of transcutaneous electrical nerve stimulation and electroacupuncture. Spine. Sep. 1983;8(6):625-34. [pmid: 6228019].
50 Leibing E, Leonhardt U, Koster G, et al. Acupuncture treatment of chronic low-back pain -- a randomized, blinded, placebo-controlled trial with 9-month follow-up. Pain. Mar. 2002;96(1-2):189-96. [pmid: 11932074].
51 Li Q, Shang W. The effect of acupuncture plus cupping on 78 cases with lumbago. Hebei Chinese Trad Med. 1997;19(5):28.
52 Li N, Wu B, Wang C-W. Comparison of acupuncture-moxibustion and physiotherapy in treating chronic non-specific low back pain. [Chinese]. Chinese J Clin Rehab. 2005;9(2):186-7.
53 Li D-J, Wang J, Gao Q, et al. Complementary effect of traction rotatory manipulation of lumbar spine and silver needle heat conductive treatment on lumbar disc herniation. [Chinese]. Chinese J Clin Rehab. 2006;10(47):8-11.
54 Lian N, Liu J-B, Torres F, et al. Improvement of dermal needle and body acupuncture on pain due to lumbar strain and hyperplastic spondylitis. Chinese J Clin Rehab. 2005;9(42):161-3.
55 Liang SY. [Observation on therapeutic effect of tendon-muscle picking therapy on myofascitis of back]. [Chinese]. Zhongguo Zhen Jiu. Aug. 2008;28(8):621-2. [pmid: 18767591].
56 Long WJ. Acupuncture treatment of acute lumbar sprain: a controlled study in 238 patients. Int J Clin Acupunct. 2000;11(1):61-4.
57 Luo S. A combined treatment of scalp acupuncture and traction in 108 cases of prolapse of the lumbar intervertebral disc. J Tradit Chin Med. Sep. 2007;27(3):178-9. [pmid: 17955652].
58 Macdonald AJ, Macrae KD, Master BR, et al. Superficial acupuncture in the relief of chronic low back pain. Ann R Coll Surg Engl. Jan. 1983;65(1):44-6. [pmid: 6218776].
59 Mencke M, Wieden TE, Hoppe M, et al. [Acupuncture of shoulder pain and low back pain. Two prospective double-blind studies]. [German]. Akupunktur. 1988;16(4):204-15.
60 Mendelson G, Kidson MA, Loh ST, et al. Acupuncture analgesia for chronic low back pain. Clin Exp Neurol. 1978;15:182-5. 1978.:182-5. [pmid: 158752].
61 Mendelson G, Selwood TS, Kranz H, et al. Acupuncture treatment of chronic back pain. A double-blind placebo-controlled trial. Am J Med. Jan. 1983;74(1):49-55. [pmid: 6217745].
62 Meng CF, Wang D, Ngeow J, et al. Acupuncture for chronic low back pain in older patients: a randomized, controlled trial. Rheumatology. Dec. 2003;42(12):1508-17. [pmid: 12890859].
63 Molsberger AF, Mau J, Pawelec DB, et al. Does acupuncture improve the orthopedic management of chronic low back pain--a randomized, blinded, controlled trial with 3 months follow up. [see comment]. Pain. Oct. 2002;99(3):579-87. [pmid: 12406534].
64 Mu JP, Cheng JM, Ao JB, et al. [Multiple central clinical test of electroacupuncture at Jiaji (EX-B 2) combined with laser needle-knife for treatment of lumbar disc herniation]. [Chinese]. Zhongguo Zhen Jiu. Aug. 2007;27(8):553-6. [pmid: 17853748].
65 Peng Y, Y, Huang Y, et al. [Clinical study on round-sharp needle therapy combined with massage for prolapse of lumbar intervertebral disk]. Zhongguo Zhen Jiu. 2006;26(OCT):719-23. [pmid: 17117572].
66 Qu Y, Mei XD, Qu H. [Control observation of therapeutic effects on syndrome of the 3rd lumbar transverse process with thick silver warming needling and electric acupuncture][Chinese]. World J Acupunct-Moxibustion. 2006;16(3):19-22.
67 Sakai T, Tsukayama H, Amagai H, et al. [Controlled trial on acupuncture for lumbago]. J Japan Soc Acupunct Moxibustion. 1998;48(1):110.
68 Sakai T, Tsutani K, Tsukayama H, et al. Multi-center randomized controlled trial of acupuncture with electric stimulation and acupuncture-like transcutaneous electricial nerve stimulation for lumbago. J Japan Soc Acupunct Moxibustion. 2001;51:175-84.
69 Sator-Katzenschlager SM, Scharbert G, Kozek-Langenecker SA, et al. The short- and long-term benefit in chronic low back pain through adjuvant electrical versus manual auricular acupuncture. [see comment]. Anesth Analg. 2004;98(5):1359-64. [pmid: 15105215].
70 She RP. [Observation on therapeutic effect of deeply needling Qiangji 4 points on prolapse of lumbar intervertebral disc]. [Chinese]. Zhongguo Zhen Jiu. May. 2008;28(5):341-4. [pmid: 18652325].
71 Takeda H, Nabeta T. [Randomized controlled trial comparing the effect of distal pint needling with local point needling for low back pain]. J Japan Soc Acupunct Moxibustion. 2001;51(3):411.
72 Tang HS. [Comparative observation of corresponding channel point selection for treatment of prolapse of lumbar intervertebral disc]. [Chinese]. Zhongguo Zhen Jiu. Aug. 2008;28(8):582-4. [pmid: 18767583].
73 Thomas M, Lundberg T. Importance of modes of acupuncture in the treatment of chronic nociceptive low back pain. Acta Anaesthesiol Scand. Jan. 1994;38(1):63-9. [pmid: 8140876].
74 Thomas KJ, MacPherson H, Ratcliffe J, et al. Longer term clinical and economic benefits of offering acupuncture care to patients with chronic low back pain. Health Technol Assess. 2005;9(32):1-109.
75 Tsui ML, Cheing GL. The effectiveness of electroacupuncture versus electrical heat acupuncture in the management of chronic low-back pain. J Altern Complement Med. Oct. 2004;10(5):803-9. [pmid: 15650469].
76 Tsukayama H, Yamashita H, Amagai H, et al. Randomised controlled trial comparing the effectiveness of electroacupuncture and TENS for low back pain: a preliminary study for a pragmatic trial. Acupunct Med. Dec. 2002;20(4):175-80. [pmid: 12512791].
77 Wang B-X, La J-L. Therapeutic effects of electro-acupuncture and diclofenic on herniation of lumbar intervertebral disc. Chinese J Clin Rehab. 2004;8(17):3413-5.
78 Wang Y. [Point-through-point acupuncture treatment of 66 patients with third lumbar vertebra transverse process syndrome] [Chinese]. Shanghai J Acupunct Moxibustion. 2004;23(2):9-10.
79 Wang Y-Q, Tang L-X, Pan C-Q. [Amelioration of ventral acupuncture therapy on the pain symptom in patients with lumbar disc herniation]. [Chinese]. Chinese J Clin Rehab. 2005;9(38):122-3.
80 Wang N. [Acupuncture plus traction therapy for lumbar intervertebral disc protrusion: Curative effect observation]. [Chinese]. J Clin Tissue Eng Res. 2007;11(25):4945-8.
81 Witt CM, Jena S, Selim D, et al. Pragmatic randomized trial evaluating the clinical and economic effectiveness of acupuncture for chronic low back pain. Am J Epidemiol. Sep 1. 2006;164(5):487-96. [pmid: 16798792].
82 Wu YC. [Clinical observations on electroacupuncture treatment of lumbar intervertebral disc protrusion] [Chinese]. Shanghai J Acupunct Moxibustion. 2004;23(5):15-7.
83 Wu Y, Liao J, Li Q. [Clinical observation on abdominal acupuncture for treatment of 114 cases of prolapse of lumbar intervertebral disc] [Chinese]. Chinese Acupunct Moxibustion. 2004;24(11):750-2.
84 Wu MQ. [Clinical observation on selection of acupoints on the same nerve segment for treatment of prolapxe of lumber intervertebral disc]. [Chinese]. Zhongguo Zhen Jiu. Jul. 2007;27(7):497-9. [pmid: 17722827].
85 Xia FX. [41 cases of prolapse of lumbar intervertebral disc treated by complex treatment] [Chinese]. Shanghai J Acupunct Moxibustion. 1997;16(5):17.
86 Yao Z. Observations on the curative effect of acupuncture and moxibustion on lumbar intervertebral disc protrusion] [Chinese]. Shanghai J Acupunct Moxibustion. 2007;26(2):25-6.
87 Ye D, Zhu H. [Treat lumbar intervertebral disc protrusion( (LIDP) by electric acupuncture traction and tuina in different stages]. J Zhejiang Coll Trad Chinese Med. 2002;26(3):60.
88 Ye Z. [Clinical studies on the treatment of lumbar intervertebral disc protrusion with a needle knife as the main method] [Chinese]. Shanghai J Acupunct Moxibustion. 2004;23(2):11-2.
89 Yeung CK, Leung MC, Chow DH. The use of electro-acupuncture in conjunction with exercise for the treatment of chronic low-back pain. J Altern Complement Med. Aug. 2003;9(4):479-90. [pmid: 14499023].
90 Yu WH, Fan WM, Cai H, et al. Clinical and mechanical studies on treatment of lumbago by needing WEIZHONG (BL40) point. Chinese Acupunct Moxibustion. 1997;17(8):503-4.
91 Yuan X, Liu C, Wang J. Clinical observation of elongated needle treatment of lumbar intervertebral disc prolapse. Int J Clin Acupunct. 2006;15(2):81-3.
92 Yuan J, Purepong N, Hunter RF, et al. Different frequencies of acupuncture treatment for chronic low back pain: an assessor-blinded pilot randomised controlled trial. Complement Ther Med. Jun. 2009;17(3):131-40. [pmid: 19398066].
93 Zeng YF. [Clinical observations on the treatment of 67 lumbar intervertebral disc protrusions by abdomen acupuncture] [Chinese]. Shanghai J Acupunct Moxibustion. 2007;26(9):16-7.
94 Zhang D-W, Liang X-F, Wang Q-J. [Clinical research on the treatment of lumbar intervertebral disc protrusion by the combination of acupuncture and massage]. Shanghai J Acupunct Moxibustion. 2002;21(2):22.
95 Zhang Z. [Observations on the curative effect of acupuncture and massage on lumbar intervertebral disc protrusion]. Shanghai J Acupunct Moxibustion. 2002;21(3):15.
96 Zhang Y, Chen F, Wu S. [Clinical observation on O3 acupoint injection for treatment of low back pain]. [Chinese]. Zhongguo Zhen Jiu. Feb. 2007;27(2):115-6. [pmid: 17370494].
97 Zhang B-M, Wu Y-C, Shao P, et al. Electro-acupuncture therapy for lumbar intervertebral disc protrusion: A randomized controlled study. [Chinese]. J Clin Tissue Eng Res. 2008;12(2):353-5.
98 Zhong B. Treatment of lumbar intervertebral disc protrusion by abdominal acupuncture plus traction] [Chinese]. Shanghai J Acupunct Moxibustion. 2006;25(6):19-20.
99 Zhou Y. [Observation of the effectiveness of prolapse of lumbar intervebral disc treated by warm needling insert Jiaji points](in Chineses). Shanghai J Acupunct Moxibustion. 1998;17(2):25.
100 Zhou ZT. [Observations on the effect of abdominal acupuncture in treating 42 cases of lumbar intervertebral disc protrusion] [Chinese]. Shanghai J Acupunct Moxibustion. 2004;23(2):13-4.
101 Zhou YL, Liu Y, et al. [Clinical study on analgesic effect of Huaisanzhen on the nerve root pain due to prolapse of lumbar intervertebral disc]. Zhongguo Zhen Jiu. 2005;25(Jan):31-3. [pmid: 16309152].
102 Zhou YL, Zhang SQ, Sun GS, et al. [Clinical observation on ankle-three-needle for treatment of nerve root pain of prolapse of lumbar intervertebral disc]. [Chinese]. Zhongguo Zhen Jiu. Dec. 2006;26(12):847-50. [pmid: 17313003].
103 Zhu Q, Li SL, Min XJ. [Clinical study on treatment of prolapse of lumbar intervertebral disc by acup-moxibustion combined with autonomic traction][Chinese]. Chinese Acupunct Moxibustion. 2003;23(10):571-3.
104 Alaksiev A, Kraev T. Postisometric relaxation versus high velocity low amplitude techniques in low back pain. Manuelle Medizin. Feb. 1996;34(1):14-7.
105 Bronfort G. Chiropractic versus general medical treatment of low back pain: a small scale controlled clinical trial. Am J Chiropractic Med. Dec. 1989;2(4):145-50.
106 Buerger AA. A controlled trial of rotational manipulation in low back pain. Manuelle Medizin. 1980;18(2):17-26.
107 Cherkin DC, Deyo RA, Battie M, et al. A comparison of physical therapy, chiropractic manipulation, and provision of an educational booklet for the treatment of patients with low back pain. [see comment]. N Eng J Med. Oct 8. 1998;339(15):1021-9.
108 Childs JD, Fritz JM, Flynn TW, et al. A clinical prediction rule to identify patients with low back pain most likely to benefit from spinal manipulation: a validation study. [see comment][summary for patients in Ann Intern Med. 2004 Dec 21;141(12):I39; PMID: 15611484]. Ann Intern Med. Dec 21. 2004;141(12):920-8. [pmid: 15611489].
109 Cote P, Mior SA, Vernon H. The short-term effect of a spinal manipulation on pain/pressure threshold in patients with chronic mechanical low back pain. J Manipulative Physiol Ther. Jul. 1994;17(6):364-8. [pmid: 7964196].
110 Dai D, Fang M, Shen G. A study on lumbar stability of degenerative spondylolisthesis treated with spine fine adjusting manipulation. [Chinese]. Chinese J of Rehab Med. 2006;21(12):1110-2.
111 Evans DP, Burke MS, Lloyd KN, et al. Lumbar spinal manipulation on trial. Part I--clinical assessment. Rheumatol Rehabil. Feb. 1978;17(1):46-53. [pmid: 153574].
112 Haas M, Groupp E, Kraemer DF. Dose-response for chiropractic care of chronic low back pain. Spine J. Sep. 2004;4(5):574-83. [pmid: 15363431].
113 Hadler NM, Curtis P, Gillings DB, et al. A benefit of spinal manipulation as adjunctive therapy for acute low-back pain: a stratified controlled trial. Spine. Sep. 1987;12(7):703-6.
114 Herzog W, Conway PJ, Willcox BJ. Effects of different treatment modalities on gait symmetry and clinical measures for sacroiliac joint patients. J Manipulative Physiol Ther. Feb. 1991;14(2):104-9. [pmid: 1826920].
115 Hoehler FK, Tobis JS, Buerger AA. Spinal manipulation for low back pain. JAMA. May 8. 1981;245(18):1835-8. [pmid: 6453240].
116 Hoiriis K. A clinical trial comparing upper cervical and full spine chiropractic care for chronic low back pain. J Chiropr Educ. 1999;13(1):67-8.
117 Hoiriis KT, Pfleger B, McDuffie FC, et al. A randomized clinical trial comparing chiropractic adjustments to muscle relaxants for subacute low back pain. J Manipulative Physiol Ther. Jul. 2004;27(6):388-98. [pmid: 15319761].
118 Hondras MA, Long CR, Cao Y, et al. A randomized controlled trial comparing 2 types of spinal manipulation and minimal conservative medical care for adults 55 years and older with subacute or chronic low back pain. J Manipulative Physiol Ther. Jun. 2009;32(5):330-43. [pmid: 19539115].
119 Hsieh CY, Adams AH, Tobis J, et al. Effectiveness of four conservative treatments for subacute low back pain: a randomized clinical trial. Spine. Jun 1. 2002;27(11):1142-8. [pmid: 12045509].
120 Lalanne K, Lafond D, Descarreaux M. Modulation of the flexion-relaxation response by spinal manipulative therapy: a control group study. J Manipulative Physiol Ther. Mar. 2009;32(3):203-9. [pmid: 19362230].
121 Mathews W, Morkel M, Mathews J. Manipulation and traction for lumbago and sciatica: Physiotherapeutic techniques used in two controlled trials. Physiother Pract. 1988;4(4):201-6.
122 Mohseni-Bandpei MA, Critchley J, Staunton T, et al. A prospective randomised controlled trial of spinal manipulation and ultrasound in the treatment of chronic low back pain. Physiotherapy. 2006;92(1):34-42.
123 Morton JE. Manipulation in the treatment of acute low back pain. J Man Manip Ther. 1999;7(4):182-9.
124 Pope MH, Phillips RB, Haugh LD, et al. A prospective randomized three-week trial of spinal manipulation, transcutaneous muscle stimulation, massage and corset in the treatment of subacute low back pain. Spine. Nov 15. 1994;19(22):2571-7. [pmid: 7855683].
125 Postacchini F, Facchini M, Palieri P. Efficacy of various forms of conservative treatment in low back pain. Neuro-Orthopedics. 1988;(6):28-35.
126 Rasmussen GG. Manipulation in treatment of low back pain (a randomized clinical trial). Manual Med. 1979;17(1):8-10.
127 Rasmussen J, Laetgaard J, Lindecrona AL, et al. Manipulation does not add to the effect of extension exercises in chronic low-back pain (LBP). A randomized, controlled, double blind study. Joint Bone Spine. Dec. 2008;75(6):708-13. [pmid: 19028434].
128 Rupert RL, Thompson P, Wagon R. Chiropractic adjustments: Results of a controlled clinical trial in Egypt. ICA Rev. May. 1985;41(3):58-60.
129 Sanders GE, Reinert O, Tepe R, et al. Chiropractic adjustive manipulation on subjects with acute low back pain: visual analog pain scores and plasma beta-endorphin levels. J Manipulative Physiol Ther. Sep. 1990;13(7):391-5. [pmid: 2145384].
130 Shearar KA, Colloca C, et al. A randomized clinical trial of the relative effectiveness of manual versus mechanical force chiropractic adjustments in the management of sacroiliac joint syndrome. J Chiropr Edu. 2004;18(SPR):29.
131 Triano JJ, McGregor M, Hondras MA, et al. Manipulative therapy versus education programs in chronic low back pain. Spine. Apr 15. 1995;20(8):948-55. [pmid: 7644961].
132 UK BEAM Trial Team. United Kingdom back pain exercise and manipulation (UK BEAM) randomised trial: effectiveness of physical treatments for back pain in primary care. [see comment]. BMJ. Dec 11. 2004;329(7479):1377. 2004. [pmid: 15556955].
133 Waagen GN, Haldeman S, Cook G, et al. Short term trial of chiropractic adjustments for the relief of chronic low back pain. Manual Med. 1986;2:63-7.
134 Zhang WB, Cao Y, Sun YA, et al. [Manipulative reduction for lumbar intervertebral disc herniation: a controlled clinical trial]. [Chinese]. Zhongguo Gushang. Apr. 2008;21(4):273-5. [pmid: 19102187].
135 Aleksiev A. Longitudinal comparative study on the outcome of inpatient treatment of low back pain with manual therapy vs. Physical therapy. J Orthopaedic Med. 1995;17(1):10-4.
136 Chiradejnant A, Latimer J, Maher CG, et al. Does the choice of spinal level treated during posteroanterior (PA) mobilisation affect treatment outcome?. Physiother Theory Pract. Dec. 2002;18(4):165-74.
137 Chiradejnant A, Maher CG, Latimer J, et al. Efficacy of “therapist-selected” versus “randomly selected” mobilisation techniques for the treatment of low back pain: a randomised controlled trial. Aust J Physiother. 2003;49(4):233-41. [pmid: 14632622].
138 Goodsell M, Lee M, Latimer J. Short-term effects of lumbar posteroanterior mobilization in individuals with low-back pain. J Manipulative Physiol Ther. Jun. 2000;23(5):332-42. [pmid: 10863253].
139 Hanrahan S, Van Lunen BL, Tamburello M, et al. The short-term effects of joint mobilizations on acute mechanical low back dysfunction in collegiate athletes. J Athl Training. 2005;40(2):88-93.
140 Hemmila HM, Keinanen-Kiukaanniemi SM, Levoska S, et al. Does folk medicine work? A randomized clinical trial on patients with prolonged back pain. Arch Phys Med Rehabil. Jun. 1997;78(6):571-7. [pmid: 9196462].
141 Hemmila HM, Keinanen-Kiukaanniemi SM, Levoska S, et al. Long-term effectiveness of bone-setting, light exercise therapy, and physiotherapy for prolonged back pain: a randomized controlled trial. J Manipulative Physiol Ther. Feb. 2002;25(2):99-104. [pmid: 11896377].
142 Konstantinou K, Foster N, Rushton A, et al. Flexion mobilizations with movement techniques: the immediate effects on range of movement and pain in subjects with low back pain. J Manipulative Physiol Ther. Mar. 2007;30(3):178-85. [pmid: 17416271].
143 Li Z-Y, Chen P-Q, Gong L, et al. Analgesic effect on lumbar intervertebral disc protrusion-induced back-leg pain by kneading method of taking the tender point as acupoint. [Chinese]. Chinese J Clin Rehab. 2006;10(23):25-7.
144 Lopez de Celis C, Barra Lopez ME, Villar ME, et al. [Effectiveness of the posteroanterior mobilization in the lumbar raquis with the Kaltenborn wedge in chronic low back pain patients]. [Spanish]. Fisioterapia. Nov-Dec. 2007;29(6):261-9. (30 ref) 2007;(6):261-9.
145 Mackawan S, Eungpinichpong W, Pantumethakul R, et al. Effects of traditional Thai massage versus joint mobilization on substance P and pain perception in patients with non-specific low back pain. J Bodywork Movement Ther. 2007;11(1):9-16.
146 Powers CM, Beneck GJ, Kulig K, et al. Effects of a single session of posterior-to-anterior spinal mobilization and press-up exercise on pain response and lumbar spine extension in people with nonspecific low back pain. Phys Ther. 2008;88(4):485-93. [pmid: 18258767].
147 Ritvanen T, Zaproudina N, Nissen M, et al. Dynamic surface electromyographic responses in chronic low back pain treated by traditional bone setting and conventional physical therapy. [erratum appears in J Manipulative Physiol Ther. 2007 Jul-Aug;30(6):472]. J Manipulative Physiol Ther. Jan. 2007;30(1):31-7. [pmid: 17224353].
148 Timm KE. A randomized-control study of active and passive treatments for chronic low back pain following L5 laminectomy. J Orthop Sports Phys Ther. 1994;20(6):276-86. [pmid: 7849747].
149 Wreje U, Nordgren B, Aberg H. Treatment of pelvic joint dysfunction in primary care--a controlled study. [erratum appears in Scand J Prim Health Care 1993 Mar;11(1):25]. Scand J Prim Health Care. Dec. 1992;10(4):310-5. [pmid: 1480873].
150 Zaproudina N, Hietikko T, Hanninen OO, et al. Effectiveness of traditional bone setting in treating chronic low back pain: a randomised pilot trial. Complement Ther Med. Jan. 2009;17(1):23-8. [pmid: 19114225].
151 Chatchawan U, Thinkhamrop B, Kharmwan S, et al. Effectiveness of traditional Thai massage versus Swedish massage among patients with back pain associated with myofascial trigger points. J Bodywork Movement Ther. 2005;9(4):298-309.
152 Farasyn A, Meeusen R, Nijs J. A pilot randomized placebo-controlled trial of roptrotherapy in patients with subacute nonspecific low back pain. J Back Musculoskeletal Rehabil. 2006;19(4):111-7.
153 Field T, Hernandez-Reif M, Diego M, et al. Lower back pain and sleep disturbance are reduced following massage therapy. J Bodywork Movement Ther. 2007;11(2):141-5.
154 Franke A, Gebauer S, Franke K, et al. [Acupuncture massage vs Swedish massage and individual exercise vs group exercise in low back pain sufferers--a randomized controlled clinical trial in a 2 x 2 factorial design]. [German]. Forsch Komplementarmed Klass Naturheilkd. Dec. 2000;7(6):286-93. [pmid: 11155022].
155 Geisser ME, Wiggert EA, Haig AJ, et al. A randomized, controlled trial of manual therapy and specific adjuvant exercise for chronic low back pain. Clin J Pain. Nov. 2005;21(6):463-70. [pmid: 16215330].
156 Hernandez-Reif M, Field T, Krasnegor J, et al. Lower back pain is reduced and range of motion increased after massage therapy. Int J Neurosci. 2001;106(3-4):131-45. [pmid: 11264915].
157 Hsieh LL, Kuo CH, Yen MF, et al. A randomized controlled clinical trial for low back pain treated by acupressure and physical therapy. Prev Med. Jul. 2004;39(1):168-76. [pmid: 15207999].
158 Hsieh LL, Kuo CH, Lee LH, et al. Treatment of low back pain by acupressure and physical therapy: randomised controlled trial. [see comment]. BMJ. Mar 25. 2006;332(7543):696-700. [pmid: 16488895].
159 Konrad K, Tatrai T, Hunka A, et al. Controlled trial of balneotherapy in treatment of low back pain. Ann Rhuem Dis. Jun. 1992;51(6):820-2.
160 Little P, Lewith G, Webley F, et al. Randomised controlled trial of Alexander technique lessons, exercise, and massage (ATEAM) for chronic and recurrent back pain. BMJ. 2008;337:a884. 2008.:a884, 2008. [pmid: 18713809].
161 Poole H, Glenn S, Murphy P. A randomised controlled study of reflexology for the management of chronic low back pain. European Journal of Pain. Nov. 2007;11(8):878-87. [pmid: 17459741].
162 Preyde M. Effectiveness of massage therapy for subacute low-back pain: a randomized controlled trial. Can Med Assoc J. Jun 27. 2000;162(13):1815-20. [pmid: 10906914].
163 Quinn F, Hughes CM, Baxter GD. Reflexology in the management of low back pain: a pilot randomised controlled trial. Complement Ther Med. Feb. 2008;16(1):3-8. [pmid: 18346622].
164 Yip YB, Tse SH. The effectiveness of relaxation acupoint stimulation and acupressure with aromatic lavender essential oil for non-specific low back pain in Hong Kong: a randomised controlled trial. Complement Ther Med. Mar. 2004;12(1):28-37. [pmid: 15130569].
165 Zhang J-F, Chen W-H. Curative effect of nonoperative therapy for the lumbar disc herniation. [Chinese]. Chinese J Clin Rehab. 2004;8(11):2006-7.
166 Aure OF, Nilsen JH, Vasseljen O. Manual therapy and exercise therapy in patients with chronic low back pain: a randomized, controlled trial with 1-year follow-up. [see comment]. Spine. Mar 15. 2003;28(6):525-31. [pmid: 12642755].
167 Farrell JP, Twomey LT. Acute low back pain. Comparison of two conservative treatment approaches. Med J Aust. Feb 20. 1982;1(4):160-4. [pmid: 6210835].
168 Ferreira ML, Ferreira PH, Latimer J, et al. Comparison of general exercise, motor control exercise and spinal manipulative therapy for chronic low back pain: A randomized trial. Pain. Sep. 2007;131(1-2):31-7. [pmid: 17250965].
169 Hancock MJ, Maher CG, Latimer J, et al. Assessment of diclofenac or spinal manipulative therapy, or both, in addition to recommended first-line treatment for acute low back pain: a randomised controlled trial. [see comment]. Lancet. Nov 10. 2007;370(9599):1638-43. [pmid: 17993364].
170 Hurley DA, McDonough SM, Dempster M, et al. A randomized clinical trial of manipulative therapy and interferential therapy for acute low back pain. Spine. Oct 15. 2004;29(20):2207-16. [pmid: 15480130].
171 Hurwitz EL, Morgenstern H, Kominski GF, et al. A randomized trial of chiropractic and medical care for patients with low back pain: eighteen-month follow-up outcomes from the UCLA low back pain study. Spine. Mar 15. 2006;31(6):611-21. [pmid: 16540862].
172 Koes BW, Bouter LM, van MH, et al. A blinded randomized clinical trial of manual therapy and physiotherapy for chronic back and neck complaints: physical outcome measures. [see comment]. J Manipulative Physiol Ther. Jan. 1992;15(1):16-23. [pmid: 1531487].
173 MacDonald RS, Bell CMJ. An open controlled assessment of osteopathic manipulation in nonspecific low-back pain. Spine. 1990;15(5):364-70. [pmid: 2141951].
174 Meade TW, Dyer S, Browne W, et al. Low back pain of mechanical origin: randomized comparison of chiropractic and hospital outpatient treatment. J Orthop Sports Phys Ther. 1991;13(6):278-87. [pmid: 18784399].
175 Sims-Williams H, Jayson MI, Young SM, et al. Controlled trial of mobilisation and manipulation for low back pain: hospital patients. BMJ. Nov 24. 1979;2(6201):1318-20. [pmid: 160266].
176 Beyerman KL, Palmerino MB, Zohn LE, et al. Efficacy of treating low back pain and dysfunction secondary to osteoarthritis: chiropractic care compared with moist heat alone. J Manipulative Physiol Ther. Feb. 2006;29(2):107-14. [pmid: 16461169].
177 Cambron JA, Gudavalli MR, Hedeker D, et al. One-year follow-up of a randomized clinical trial comparing flexion distraction with an exercise program for chronic low-back pain. J Altern Complement Med. Sep. 2006;12(7):659-68. [pmid: 16970536].
178 Hawk C, Azad A, Phongphua C, et al. Preliminary study of the effects of a placebo chiropractic treatment with sham adjustments. [see comment]. J Manipulative Physiol Ther. Sep. 1999;22(7):436-43. [pmid: 10519559].
179 Hawk C, Long CR, Rowell RM, et al. A randomized trial investigating a chiropractic manual placebo: a novel design using standardized forces in the delivery of active and control treatments. J Altern Complement Med. Feb. 2005;11(1):109-17. [pmid: 15750369].
180 Abernethy AP. Randomized controlled trial of acupuncture for chronic neck pain. J Pain Palliat Care Pharmacother. 2008;(2):145-6. [pmid: 19042839].
181 Aigner N, Fialka C, Stocker R, et al. [Acupuncture versus laser acupuncture in the treatment of whiplash injury - A prospective randomized study.] [German]. Dtsch Z Akupunkt. 1999;42(1):4-12.
182 Allison GT, Nagy BM, Hall T. A randomized clinical trial of manual therapy for cervico-brachial pain syndrome -- a pilot study. Man Ther. May. 2002;7(2):95-102. [pmid: 12151246].
183 Bin X, Ling F, Lingxiang H. Clinical observation on cervical spondylopathy of the vertebroarterial type treated by electro-acupuncture. J Tradit Chin Med. 2007;27(1):39-42. [pmid: 17393625].
184 Birch S, Jamison RN. Controlled trial of Japanese acupuncture for chronic myofascial neck pain: assessment of specific and nonspecific effects of treatment. Clin J Pain. Sep. 1998;14(3):248-55. [pmid: 9758075].
185 Ceccherelli F, Tortora P, Nassimbeni C, et al. The therapeutic efficacy of somatic acupuncture is not increased by auriculotherapy: a randomised, blind control study in cervical myofascial pain. Complement Ther Med. Mar. 2006;14(1):47-52. [pmid: 16473753].
186 Chu J. Does EMG (dry needling) reduce myofascial pain symptoms due to cervical nerve root irritation?. Electroencephalogr Clin Neurophysiol. Aug. 1997;37(5):259-72.
187 Coan RM, Wong G, Coan PL. The acupuncture treatment of neck pain: a randomized controlled study. Am J Chinese Med. 1981;9(4):326-32.
188 David J, Modi S, Aluko AA, et al. Chronic neck pain: a comparison of acupuncture treatment and physiotherapy. Br J Rheumatol. Oct. 1998;37(10):1118-22. [pmid: 9825752].
189 Edwards J, Knowles N. Superficial dry needling and active stretching in the treatment of myofascial pain--a randomised controlled trial. Acupunct Med. Sep. 2003;21(3):80-6. [pmid: 14620302].
190 Fu WB, Zhang HL, Fan L. [Treatment of cervical spondylopathy by needle pricking: A clinical observation of 56 cases] [Chinese]. New J Tradit Chinese Med. 2005;37(4):65-6.
191 Fu ZH, Wang JH, Sun JH, et al. Fu's subcutaneous needling: possible clinical evidence of the subcutaneous connective tissue in acupuncture. J Altern Complement Med. Jan. 2007;13(1):47-51. [pmid: 17309377].
192 Ga H, Choi JH, Park CH, et al. Acupuncture needling versus lidocaine injection of trigger points in myofascial pain syndrome in elderly patients--a randomised trial. Acupunct Med. Dec. 2007;25(4):130-6. [pmid: 18160923].
193 Gallacchi G, Muller W. [Acupuncture--does it contribute anything?]. [German]. Schweiz Rundsch Med Prax. May 31. 1983;72(22):778-82. [pmid: 6224144].
194 Huang YF, Wang TF, Liu Y, et al. [Clinical observation on Jiquan (HT 1) for treatment of cervical spondylosis of nerve root type]. [Chinese]. Zhongguo Zhen Jiu. Jun. 2008;28(6):427-8. [pmid: 18630541].
195 Ilbuldu E, Cakmak A, Disci R, et al. Comparison of laser, dry needling, and placebo laser treatments in myofascial pain syndrome. Photomed Laser Surg. Aug. 2004;22(4):306-11. [pmid: 15345173].
196 Irnich D, Behrens N, Molzen H, et al. Randomised trial of acupuncture compared with conventional massage and “sham” laser acupuncture for treatment of chronic neck pain. [see comment]. BMJ. Jun 30. 2001;322(7302):1574-8. [pmid: 11431299].
197 Itoh K, Katsumi Y, Hirota S, et al. Randomised trial of trigger point acupuncture compared with other acupuncture for treatment of chronic neck pain. Complement Ther Med. Sep. 2007;15(3):172-9. [pmid: 17709062].
198 Jia CS, Shi J, Ma XS, et al. [Comparison of the analgesic effect of acupuncture between otopoint-penetrative needling and otopoint-straight needling for cervical type and nerve-root type cervicospondylopathy]. [Chinese]. Chen Tzu Yen Chiu. 2007;32(3):186-9. [pmid: 17691577].
199 Li XH. [Therapeutic effect of centro-square needling Dazhui (GV 14) on cervical spondylosis] [Chinese]. Chinese Acupunct Moxibustion. 2004;24(7):455-6.
200 Li D-J, Wang J, Gao Q, et al. Interventional effects of cervical local-point traction manipulation plus silver needle heat conductive treatment for cervical spinal canal stenosis. [Chinese]. Chinese J Clin Rehab. 2006;10(43):7-10.
201 Liang ZH, Yang YH, Yu P, et al. [Logistic regression analysis on therapeutic effect of acupuncture on neck pain caused by cervical spondylosis and factors influencing therapeutic effect]. Zhongguo Zhen Jiu. Mar. 2009;29(3):173-6. [pmid: 19358495].
202 Lin M-N, Liu X-X, Liu J-H, et al. Needle scalpel combined with massage therapy and simple massage therapy for nerve-root type cervical spondylopathy: A randomized controlled analysis on 100 patients. Chinese J Clin Rehab. 2004;8(23):4920-1.
203 Lu YX, Shan QH. [Clinical observation on treatment of cervicogenic headache with turtle-probing needling at Tianzhu (BL 10)]. [Chinese]. Zhongguo Zhen Jiu. Nov. 2006;26(11):796-8. [pmid: 17165503].
204 Lundeberg T, Eriksson SV, Lundeberg S, et al. Effect of acupuncture and naloxone in patients with osteoarthritis pain. A sham acupuncture controlled study. Pain Clinic. 1991;4(3):155-61.
205 Nabeta T, Kawakita K. Relief of chronic neck and shoulder pain by manual acupuncture to tender points--a sham-controlled randomized trial. Complement Ther Med. Dec. 2002;10(4):217-22. [pmid: 12594972].
206 Petrie JP, Langley GB. Acupuncture in the treatment of chronic cervical pain. A pilot study. Clin Exp Rheumatol. Oct. 1983;1(4):333-6. [pmid: 6335859].
207 Petrie JP, Hazleman BL. A controlled study of acupuncture in neck pain. Br J Rheumatol. Aug. 1986;25(3):271-5. [pmid: 3524727].
208 Salter GC, Roman M, Bland MJ, et al. Acupuncture for chronic neck pain: a pilot for a randomised controlled trial. BMC Musculoskelet Disord. 2006;7:99. [pmid: 17156464].
209 Sator-Katzenschlager SM, Szeles JC, Scharbert G, et al. Electrical stimulation of auricular acupuncture points is more effective than conventional manual auricular acupuncture in chronic cervical pain: a pilot study. Anesth Analg. Nov. 2003;97(5):1469-73. [pmid: 14570667].
210 Seidel U, Uhlemann C. [A randomised controlled double-blind trial comparing dosed lasertherapy on acupuncture points and acupuncture for chronic cervical syndrome]. [German]. Dtsch Z Akupunkt. 2002;45(4):258-69.
211 Shang X, Meng X, Dong H, et al. [Clinical observations on the treatment of nerve-root cervical spondylopathy by the combination of adjacent and remote acupoints] [Chinese]. Shanghai J Acupunct Moxibustion. 2002;21(6):12-3.
212 Vas J, Perea-Milla E, Mendez C, et al. Efficacy and safety of acupuncture for chronic uncomplicated neck pain: a randomised controlled study. Pain. Dec 15. 2006;126(1-3):245-55. [pmid: 16934402].
213 Venancio RA, Alencar FG, Zamperini C. Different substances and dry-needling injections in patients with myofascial pain and headaches. Cranio. Apr. 2008;26(2):96-103. [pmid: 18468269].
214 Wang XL, Huang HY. [Observation on therapeutic effect of long-time needle retention at Baihui (GV 20) on vertebroarterial cervical spondylopathy]. [Chinese]. Zhongguo Zhen Jiu. Jun. 2007;27(6):415-6. [pmid: 17663103].
215 Wang C, Xiong Z, Deng C, et al. Miniscalpel-needle versus triggerpoint injection for cervical myofascial pain syndrome: a randomized comparative trial. [see comment]. J Altern Complement Med. Jan. 2007;13(1):14-6. [pmid: 17309371].
216 Wang XL. [Observation on therapeutic effect of shu-needling therapy as main on cervical spondylosis of nerve root type]. [Chinese]. Zhongguo Zhen Jiu. Jul. 2008;28(7):497-8. [pmid: 18678161].
217 White PF, Craig WF, Vakharia AS, et al. Percutaneous neuromodulation therapy: Does the location of electrical stimulation effect the acute analgesic response?. Anesth Analg. 2000;91(4):949-54. [pmid: 11004055].
218 White P, Lewith G, Prescott P, et al. Acupuncture versus placebo for the treatment of chronic mechanical neck pain: a randomized, controlled trial. [see comment][summary for patients in Ann Intern Med. 2004 Dec 21;141(12):I26; PMID: 15611483]. Ann Intern Med. Dec 21. 2004;141(12):911-9. [pmid: 15611488].
219 Witt CM, Jena S, Brinkhaus B, et al. Acupuncture for patients with chronic neck pain. Pain. Nov. 2006;125(1-2):98-106. [pmid: 16781068].
220 Yang T, Sun F, Zhou YL. [Clinical observation on acupoint sticking therapy for treatment of chronic pain of cervical intervertebral disc]. Zhongguo Zhen Jiu. Mar. 2009;29(3):197-9. [pmid: 19358501].
221 Zeng L. [Treatment of cervical spondylopathy by point-through-point Acupuncture] [Chinese]. Shanghai J Acupunct Moxibustion. 2005;24(7):9-10.
222 Zhang HL. [A randomized controlled trial of electroacupuncture and traction for treatment of nerve-root type cervical spondylosis][Chinese]. Chinese Acupunct Moxibustion. 2003;23(11):637-9.
223 Zhang W, Zheng J, Zhao X. Treatment of arterial-type cervical spondylosis with acupoint-injection, combined with massage manipulation. Int J Clin Acupunct. 2005;14(4):261-5.
224 Zhao ZY, Cai D, Liang F. [Observation on therapeutic effect of Shencongding moxibustion on cervical headache] [Chinese]. Chinese Acupunct Moxibustion. 2004;24(6):389-91.
225 Zhu XM, Polus B. A controlled trial on acupuncture for chronic neck pain. Am J Chinese Med. 2002;30(1):13-28.
226 Zhu HZ, Quan WC, Zhang XF, et al. [Evaluation on clinical therapeutic effect of needle-knife therapy on cervical spondylosis]. [Chinese]. Zhongguo Zhen Jiu. May. 2006;26(5):316-8. [pmid: 16739840].
227 Zhuang L-X, Zhu F-P. [Effect of pressed acupuncture at baihui acupoint on thromboxane A^2^ and prostacyclin in treating vertebral artery type of cervical spondylosis]. [Chinese]. Chinese J Clin Rehab. 2004;8(30):6672-3.
228 Bischoff A, Nurnberger A, Voigt P, et al. Osteopathy alleviates pain in chronic nonspecific neck pain: randomized controlled trial. Focus Altern Complement Ther. 2003;8(4):537.
229 Buchmann J, Wende K, Kundt G, et al. Manual treatment effects to the upper cervical apophysial joints before, during, and after endotracheal anesthesia: A placebo-controlled comparison. Am J Phys Med Rehabil. 2005;84(4):251-7. [pmid: 15785257].
230 Cassidy JD, Lopes AA, Yong-Hing K. The immediate effect of manipulation versus mobilization on pain and range of motion in the cervical spine: a randomized controlled trial. [see comment]. J Manipulative Physiol Ther. Nov. 1992;15(9):570-5. [pmid: 1469341].
231 Chen L, Zhang X-L, Ding H, et al. Comparative study on effects of manipulation treatment and transcutaneous electrical nerve stimulation on patients with cervicogenic headache. [Chinese]. J Chin Integrative Med. 2007;5(4):403-6.
232 Cilliers KI, Penter CS. Relative effectiveness of two different approaches to adjust a fixated segment in the treatment of facet syndrome in the cervical spine. JNMS. 1998;(1):1-5.
233 Cleland J. Immediate effects of throacic spine manipulation in patients with neck pain: A randomized clinical trial. J Man Manip Ther. 2004;(12):162.
234 Cleland JA, Childs JD, McRae M, et al. Immediate effects of thoracic manipulation in patients with neck pain: a randomized clinical trial. [see comment]. Man Ther. May. 2005;10(2):127-35. [pmid: 15922233].
235 Cleland JA, Glynn P, Whitman JM, et al. Short-term effects of thrust versus nonthrust mobilization/manipulation directed at the thoracic spine in patients with neck pain: a randomized clinical trial. Phys Ther. Apr. 2007;87(4):431-40. [pmid: 17341509].
236 Eqwu MO. Relative therapeutic efficacy of some vertebral mobolization techniques in the management of unilateral cervical spondylosis: a comparitive study. J Phys Ther Sci. 2008;20:103-8.
237 Fernandez-de-Las-Penas C, Fernandez-Carnero J, Fernandez AP, et al. Dorsal manipulation in whiplash injury treatment: A randomized controlled trial. J Whiplash Relat Disord. 2004;3(2):55-72.
238 Gonzalez-Iglesias J, Fernandez-de-Las-Penas C, Cleland JA, et al. Thoracic spine manipulation for the management of patients with neck pain: a randomized clinical trial. J Orthop Sports Phys Ther. Jan. 2009;39(1):20-7. [pmid: 19209478].
239 Haas M, Groupp E, Panzer D, et al. Efficacy of cervical endplay assessment as an indicator for spinal manipulation. [see comment]. Spine. Jun 1. 2003;28(11):1091-6. [pmid: 12782973].
240 Haas M, Groupp E, Aickin M, et al. Dose response for chiropractic care of chronic cervicogenic headache and associated neck pain: a randomized pilot study. J Manipulative Physiol Ther. Nov. 2004;27(9):547-53. [pmid: 15614241].
241 Hurwitz EL, Morgenstern H, Harber P, et al. A randomized trial of chiropractic manipulation and mobilization for patients with neck pain: clinical outcomes from the UCLA neck-pain study. [see comment]. Am J Public Health. Oct. 2002;92(10):1634-41. [pmid: 12356613].
242 Krauss J, Creighton D, Ely JD, et al. The immediate effects of upper thoracic translatoric spinal manipulation on cervical pain and range of motion: A randomized clinical trial. J Man Manip Ther. 2008;16(2):93-9. [pmid: 19119394].
243 Martinez-Segura R, Fernandez-de-Las-Penas C, Ruiz-Saez M, et al. Immediate effects on neck pain and active range of motion after a single cervical high-velocity low-amplitude manipulation in subjects presenting with mechanical neck pain: a randomized controlled trial. J Manipulative Physiol Ther. Sep. 2006;29(7):511-7. [pmid: 16949939].
244 Metcalfe S, Reese H, Sydenham R. Effect of high-velocity low-amplitude manipulation on cervical spine muscle strength: A randomized clinical trial. J Man Manip Ther. 2006;14(3):152-8.
245 Nilsson N, Christensen HW, Hartvigsen J. The effect of spinal manipulation in the treatment of cervicogenic headache. J Manipulative Physiol Ther. Jun. 1997;20(5):326-30. [pmid: 9200048].
246 Parkin-Smith GF, Penter CS. A clinical trial investigating the effect of two manipulative approaches in the treatment of mechanical neck pain: a pilot study. JNMS. 1998;(1):6-16.
247 Pikula JR. The effect of spinal manipulative therapy (SMT) on pain reduction and range of motion in patients with acute unilateral neck pain: a pilot study. J Can Chiropract Assoc. Jun. 1999;43(2):111-9.
248 Sloop PR, Smith DS, Goldenberg E, et al. Manipulation for chronic neck pain. A double-blind controlled study. Spine. Nov. 1982;7(6):532-5. [pmid: 6762670].
249 Strunk RG, Hondras MA. A feasibility study assessing manual therapies to different regions of the spine for patients with subacute or chronic neck pain. J Chiropractic Med. Mar. 2008;7(1):1-8.
250 van Schalkwyk R, Parkin-Smith GF. A clinical trial investigating the possible effect of the supine cervical rotatory manipulation and the supine lateral break manipulation in the treatment of mechanical neck pain: a pilot study. [see comment]. J Manipulative Physiol Ther. Jun. 2000;23(5):324-31. [pmid: 10863252].
251 Vernon HT, Aker P, Burns S, et al. Pressure pain threshold evaluation of the effect of spinal manipulation in the treatment of chronic neck pain: a pilot study. J Manipulative Physiol Ther. Jan. 1990;13(1):13-6. [pmid: 2324655].
252 Whittingham W, Nilsson N. Active range of motion in the cervical spine increases after spinal manipulation (toggle recoil). J Manipulative Physiol Ther. Nov. 2001;24(9):552-5. [pmid: 11753327].
253 Yurkiw D, Mior S. Comparison of two chiropractic techniques on pain and lateral flexion in neck pain patients: a pilot study. Chiropractic Technique. Nov. 1996;8(4):155-62. (25 ref) 1996;(4):155-62.
254 Brodin H. Cervical pain and mobilization. Acta Belgica - Medica Physica. Apr. 1983;6(2):67-72.
255 Coppieters MW, Stappaerts KH, Wouters LL, et al. Aberrant protective force generation during neural provocation testing and the effect of treatment in patients with neurogenic cervicobrachial pain. J Manipulative Physiol Ther. 2003;26(2):99-106. [pmid: 12584508].
256 Hemmila HM. Bone setting for prolonged neck pain: a randomized clinical trial. J Manipulative Physiol Ther. Sep. 2005;28(7):508-15. [pmid: 16182025].
257 Hoving JL, de Vet HC, Koes BW, et al. Manual therapy, physical therapy, or continued care by the general practitioner for patients with neck pain: long-term results from a pragmatic randomized clinical trial. Clin J Pain. May. 2006;22(4):370-7. [pmid: 16691091].
258 Kanlayanaphotporn R, Chiradejnant A, Vachalathiti R. The immediate effects of mobilization technique on pain and range of motion in patients presenting with unilateral neck pain: a randomized controlled trial. Arch Phys Med Rehab. Feb. 2009;90(2):187-92.
259 Sterling M, Jull G, Wright A. Cervical mobilisation: concurrent effects on pain, sympathetic nervous system activity and motor activity. Man Ther. May. 2001;6(2):72-81. [pmid: 11414776].
260 Zaproudina N, Hanninen OO, Airaksinen O. Effectiveness of traditional bone setting in chronic neck pain: randomized clinical trial. J Manipulative Physiol Ther. Jul. 2007;30(6):432-7. [pmid: 17693333].
261 Blikstad A, Gemmell H. Immediate effect of activator trigger point therapy and myofascial band therapy on non-specific neck pain in patients with upper trapezius trigger points compared to sham ultrasound: A randomised controlled trial. Clinical Chiropractic. Mar. 2008;11(1):23-9.
262 Cen SY, Loy SF, Sletten EG, et al. The effect of traditional Chinese Therapeutic Massage on individuals with neck pain. Clin Acupunct Orient Med. 2003;4(2-3):88-93.
263 Fernandez-de-Las-Penas C, Alonso-Blanco C, Fernandez-Carnero J, et al. The immediate effect of ischemic compression technique and transverse friction massage on tenderness of active and latent myofascial trigger points: A pilot study. J Bodywork Movement Ther. 2006;10(1):3-9.
264 Gemmell H, Miller P, Nordstrom H. Immediate effect of ischaemic compression and trigger point pressure release on neck pain and upper trapezius trigger points: A randomised, controlled trial. Clinical Chiropractic. Mar. 2008;11(1):30-6.
265 Hanten WP, Barrett M, Gillespie-Plesko M, et al. Effects of active head retraction with retraction/extension and occipital release on the pressure pain threshold of cervical and scapular trigger points. Physiother Theory Pract. 1997;13(4):285-91.
266 Meseguer AA, Fernandez-de-Las-Penas C, Navarro-Poza JL, et al. Immediate effects of the strain/counterstrain technique in local pain evoked by tender points in the upper trapezius muscle. Clinical Chiropractic. Sep. 2006;9(3):112-8. (24 ref) 2006;9(3):112-8.
267 Sherman KJ, Cherkin DC, Hawkes RJ, et al. Randomized trial of therapeutic massage for chronic neck pain. Clin J Pain. Mar. 2009;25(3):233-8. [pmid: 19333174].
268 Yagci N, Uygur F, Bek N. Comparison of connective tissue massage and spray-and-stretch technique in the treatment of chronic cervical myofascial pain syndrome. Pain Clinic. 2004;16(4):469-74.
269 Zhang Y-Z, Wang X-H, Xing H-Y, et al. Mechanical effects of traction and massage therapy on cervical spondylopathy. Chinese J Clin Rehab. 2005;9(42):159-61.
270 Carlsson J, Fahlcrantz A, Augustinsson LE. Muscle tenderness in tension headache treated with acupuncture or physiotherapy. Cephalalgia : an international journal of headache. 1990;10(3):131-41. [pmid: 2245458].
271 Schiller L. Effectiveness of spinal manipulative therapy in the treatment of mechanical thoracic spine pain: a pilot randomized clinical trial. [see comment]. J Manipulative Physiol Ther. Jul. 2001;24(6):394-401. [pmid: 11514816].
272 Hollinghurst S, Sharp D, Ballard K, et al. Randomised controlled trial of Alexander technique lessons, exercise, and massage (ATEAM) for chronic and recurrent back pain: economic evaluation. BMJ. 2008;337:a2656. [pmid: 19074232].
273 Kominski GF, Heslin KC, Morgenstern H, et al. Economic evaluation of four treatments for low-back pain: results from a randomized controlled trial. [see comment]. Med Care. May. 2005;43(5):428-35. [pmid: 15838406].
274 Hurwitz EL, Morgenstern H, Yu F. Satisfaction as a predictor of clinical outcomes among chiropractic and medical patients enrolled in the UCLA low back pain study. Spine. Oct 1. 2005;30(19):2121-8. [pmid: 16205336].
275 Goldstein MS, Morgenstern H, Hurwitz EL, et al. The impact of treatment confidence on pain and related disability among patients with low-back pain: results from the University of California, Los Angeles, low-back pain study. Spine J. Nov. 2002;2(6):391-9. [pmid: 14589256].
276 Hurwitz EL, Morgenstern H, Harber P, et al. A randomized trial of medical care with and without physical therapy and chiropractic care with and without physical modalities for patients with low back pain: 6-month follow-up outcomes from the UCLA low back pain study. [see comment]. Spine. Oct 15. 2002;27(20):2193-204. [pmid: 12394892].
277 Hertzman-Miller RP, Morgenstern H, Hurwitz EL, et al. Comparing the satisfaction of low back pain patients randomized to receive medical or chiropractic care: results from the UCLA low-back pain study. Am J Public Health. Oct. 2002;92(10):1628-33. [pmid: 12356612].
278 Hurwitz EL, Morgenstern H, Harber P, et al. The effectiveness of physical modalities among patients with low back pain randomized to chiropractic care: Findings from the UCLA low back pain study. J Manipulative Physiol Ther. 2002;25(1):10-20. [pmid: 11898014].
279 Hurwitz EL, Morgenstern H, Harber PI, et al. Effectiveness of physical modalities among low back pain patients randomized to chiropractic care: findings from the UCLA low-back pain study. Eur J Chiropr. 2002;49(1):102-3.
280 Hoving JL, Korthals-de B I, De VH, et al. The effects and costs of manual therapy, physiotherapy and treatment by the general practitioner in neck disorders: A randomized clinical experiment. [Dutch]. Huisarts en Wetenschap. 2004;47(5):218-26.
281 Seferlis T, Lindholm L, Nemeth G. Cost-minimisation analysis of three conservative treatment programmes in 180 patients sick-listed for acute low-back pain. Scand J Prim Health Care. Mar. 2000;18(1):53-7. [pmid: 10811045].
282 Seferlis T, Nemeth G, Carlsson AM, et al. Conservative treatment in patients sick-listed for acute low-back pain: a prospective randomised study with 12 months' follow-up. Eur Spine J. 1998;7(6):461-70. [pmid: 9883955].
283 Niemisto L, Lahtinen-Suopanki T, Rissanen P, et al. A randomized trial of combined manipulation, stabilizing exercises, and physician consultation compared to physician consultation alone for chronic low back pain. Spine. Oct 1. 2003;28(19):2185-91. [pmid: 14520029].
284 Ratcliffe J, Thomas KJ, MacPherson H, et al. A randomised controlled trial of acupuncture care for persistent low back pain: cost effectiveness analysis. [see comment]. BMJ. Sep 23. 2006;333(7569):626. 2006. [pmid: 16980315].
285 Thomas KJ, MacPherson H, Thorpe L, et al. Randomised controlled trial of a short course of traditional acupuncture compared with usual care for persistent non-specific low back pain. [see comment]. BMJ. Sep 23. 2006;333(7569):623. 2006. [pmid: 16980316].
286 Thomas K, MacPherson H, Ratcliffe J, et al. A short course of acupuncture is a cost-effective intervention for low back pain in primary care. Results from a pragmatic randomised controlled.[record]. Cochrane Library. 2009;(4):CN-00519332.
287 Thorpe L, Thomas K, Fitter M, et al. Early results from a pragmatic randomised controlled trial demonstrate acceptability and potential effectiveness of acupuncture as a treatment for low back pain [abstract]. The Challenge of Collaboration Proceedings of the 18th Annual Meeting of the International Society of Technology Assessment in Health Care. Jun 9 12 2002. 2002:204.
288 MacPherson H. Acupuncture and low back pain: Results from a pragmatic randomised controlled trial. J Altern Complement Med. 2004;10(1):204-5.
289 Thorpe L, Thomas KJ, Fitter M, et al. Acupuncture in the management of persistent low back pain: findings to date of a pragmatic, randomised controlled trial. Focus Altern Complement Ther. 2002;7(1):113.
290 MacPherson H, Thomas K, Brazier J, et al. Longer term clinical and economic benefits of offering acupuncture to patients with chronic low back pain assessed as suitable for primary care management - 3 month clinical outcomes from a controlled trial of 241 patients. Acupunct Med. 2002;20(3-Feb):121.
291 Thomas K, Thorpe L, MacPherson H. Preliminary findings from a pragmatic randomised controlled trial demonstrate acceptability of acupuncture as a treatment for low back pain. Clin Acupunct Orient Med. 2003;4(1):56.
292 Thomas KJ, MacPherson H, Ratcliffe J, et al. Longer term clinical and economic benefits of offering acupuncture care to patients with chronic low back pain (Structured abstract). Health Technol Assess. 2005;140.
293 Witt CM, Brinkhaus B, Reinhold T, et al. Efficacy, effectiveness, safety and costs of acupuncture for chronic pain - Results of a large research initiative. Acupunct Med. Suppl. 2006;24:S33-S39.
294 Witt C, Selim D, Reinhold T, et al. Cost-effectiveness of acupuncture in patients with headache, low back pain and osteoarthritis of the hip and the knee. 12th Annual Symposium on Complementary Health Care -- Abstracts. 19th-21st September 2005. Exeter, UK. Focus Altern Complement Ther. 2005:57-8.
295 UK BEAM Trial Team. United Kingdom back pain exercise and manipulation (UK BEAM) randomised trial: cost effectiveness of physical treatments for back pain in primary care. [see comment]. BMJ. Dec 11. 2004;329(7479):1381. 2004. [pmid: 15556954].
296 Ernst E, Tillett R, Tveito TH, et al. United Kingdom back pain exercise and manipulation (UK BEAM) trial... UK BEAM Trial Team. United Kingdom back pain exercise and manipulation (UK BEAM) randomised trial: effectiveness of physical treatments for back pain in primary care. BMJ. 2004;329(11 December):1377-81. BMJ 2005 Mar 19; 330(7492): 673-4 (11 ref) 2005;(7492):673-4. [pmid: 15556955].
297 Korthals de Bos I, Hoving JL, van Tulder MW, et al. Cost effectiveness of physiotherapy, manual therapy, and general practitioner care for neck pain: economic evaluation alongside a randomised controlled trial. [see comment]. BMJ. Apr 26. 2003;326(7395):911. 2003. [pmid: 12714472].
298 Lewis M, James M, Stokes E, et al. An economic evaluation of three physiotherapy treatments for non-specific neck disorders alongside a randomized trial. Rheumatology. Nov. 2007;46(11):1701-8. [pmid: 17956916].
299 Dziedzic K, Hill J, Lewis M, et al. Effectiveness of manual therapy or pulsed shortwave diathermy in addition to advice and exercise for neck disorders: a pragmatic randomized controlled trial in physical therapy clinics. Arthrit Rheum. Apr 15. 2005;53(2):214-22.
300 Willich SN, Reinhold T, Selim D, et al. Cost-effectiveness of acupuncture treatment in patients with chronic neck pain. Pain. Nov. 2006;125(1-2):107-13. [pmid: 16842918].
301 Cassidy JD, Boyle E, Cote P, et al. Risk of vertebrobasilar stroke and chiropractic care: results of a population-based case-control and case-crossover study. J Manipulative Physiol Ther. Feb. 2 Suppl. 2009;32:S201-S208. [pmid: 19251066].
302 Kohlbeck FJ, Haldeman S, Hurwitz EL, et al. Supplemental care with medication-assisted manipulation versus spinal manipulation therapy alone for patients with chronic low back pain. J Manipulative Physiol Ther. May. 2005;28(4):245-52. [pmid: 15883577].
303 Cook C, Cook A, Worrell T. Manual therapy provided by physical therapists in a hospital-based setting: a retrospective analysis. J Manipulative Physiol Ther. Jun. 2008;31(5):338-43. [pmid: 18558275].
304 Mulligan BR. Manual therapy: Nags Snags MWMS etc. Wellington, NZ. Plane View Services. 1999.
305 Smith WS, Johnston SC, Skalabrin EJ, et al. Spinal manipulative therapy is an independent risk factor for vertebral artery dissection. [see comment]. Neurology. May 13. 2003;60(9):1424-8. [pmid: 12743225].