# Quality Assessment Forms

Table 1 Updated Method Guidelines for Systematic Reviews in the Cochrane Collaboration Back Review Group – A 12 Item tool.

Item | Rating
Was the method of randomization adequate? | Yes / No / Unsure
Was the treatment allocation concealed? | Yes / No / Unsure
Were the groups similar at baseline regarding the most important prognostic indicators? | Yes / No / Unsure
Was the patient blinded to the intervention? | Yes / No / Unsure
Was the care provider blinded to the intervention? | Yes / No / Unsure
Was the outcome assessor blinded to the intervention? | Yes / No / Unsure
Were co-interventions avoided or similar? | Yes / No / Unsure
Was the compliance acceptable in all groups? | Yes / No / Unsure
Was the drop-out rate described and acceptable? | Yes / No / Unsure
Was the timing of the outcome assessment in all groups similar? | Yes / No / Unsure
Did the analysis include an intention-to-treat analysis? | Yes / No / Unsure
Are reports of the study free of suggestion of selective outcome reporting? | Yes / No / Unsure

Maurits van Tulder, PhD, Andrea Furlan, MD, Claire Bombardier, MD, FRCP, Lex Bouter, PhD, and the Editorial Board of the Cochrane Collaboration Back Review Group

Table 2 Acupuncture for Chronic Low-back pain a systematic review of the literature – A 13 item tool

Item | Rating
Adequate sequence generation? | Yes / No / Unsure
Allocation concealment? | Yes / No / Unsure
Blinding? (All outcomes - patients?) | Yes / No / Unsure
Blinding? (All outcomes - providers?) | Yes / No / Unsure
Blinding? (All outcomes - outcome assessors?) | Yes / No / Unsure
Incomplete outcome data addressed? (All outcomes - drop-outs?) | Yes / No / Unsure
Incomplete outcome data addressed? (All outcomes - ITT analysis?) | Yes / No / Unsure
Free of selective reporting? | Yes / No / Unsure
Free of other bias? | Yes / No / Unsure
Similarity of baseline characteristics? | Yes / No / Unsure
Co-interventions avoided or similar? | Yes / No / Unsure
Compliance acceptable? | Yes / No / Unsure
Timing outcome assessments similar? | Yes / No / Unsure

Table 3 CHEC List- 19 item Quality assessment tool for economic studies

Item | Rating
Is the study population clearly described? | Yes / No
Are competing alternatives clearly described? | Yes / No
Is a well-defined research question posed in answerable from? | Yes / No
Is the economic study design appropriate? | Yes / No
Is the chosen time horizon appropriate in order to include? | Yes / No
Is the actual perspective chosen appropriate? | Yes / No
Are all important and relevant costs for each alternative identified? | Yes / No
Are all costs measured appropriately in physical units? | Yes / No
Are costs valued appropriately? | Yes / No
Are all important and relevant outcomes for each alternative identified? | Yes / No
Are all outcomes measured appropriately? | Yes / No
Are outcomes valued appropriately? | Yes / No
Is an incremental analysis of costs and outcomes of alternatives performed? | Yes / No
Are all future costs and outcomes discounted appropriately? | Yes / No
Are all important variables shoes values are uncertain appropriately subjected to sensitivity analysis? | Yes / No
Do the conclusions follow from the data reported? | Yes / No
Does the study discuss the general izabi lity of the results to other setting and patient groups? | Yes / No
Does the article indicate that there is no potential conflict of interest of study researcher(s) and funder(s)? | Yes / No
Are ethical and distributional issues discussed appropriately? | Yes / No

Table 4 The McGill Pain Questionnaire

Overview: The McGill Pain Questionnaire can be used to evaluate a person experiencing significant pain. It can be used to monitor the pain over time and to determine the effectiveness of any intervention. It was developed at by Dr. Melzack at McGill University in Montreal Canada and has been translated into several languages.

Sections:
1. What Does Your Pain Feel Like?
2. How Does Your Pain Change with Time?
3. How Strong is Your Pain?

1 What Does Your Pain Feel Like?

Statement: Some of the following words below describe your [underlined: present] pain. Circle [underlined: ONLY] those words that best describe it. Leave out any category that is not suitable. Use only a single word in each appropriate category - the one that applies best.

Group | Descriptor | Points
1 (temporal) | Flickering | 1
| Quivering | 2
| Pulsing | 3
| Throbbing | 4
| Beating | 5
| Pounding | 6
2 (spatial) | Jumping | 1
| Flashing | 2
| Shooting | 3
3 (punctate pressure) | Pricking | 1
| Boring | 2
| Drilling | 3
| Stabbing | 4
| Lancinating | 5
4 (incisive pressure) | Sharp | 1
| Cutting | 2
| lacerating | 3
5 (constrictive pressure) | Pinching | 1
| Pressing | 2
| Gnawing | 3
| Cramping | 4
| Crushing | 5
6 (traction pressure) | Tugging | 1
| Pulling | 2
| Wrenching | 3
7 (thermal) | Hot | 1
| Boring | 2
| Scalding | 3
| Searing | 4
8 (brightness) | Tingling | 1
| Itchy | 2
| Smarting | 3
| Stinging | 4
9 (dullness) | Dull | 1
| Sore | 2
| Hurting | 3
| Aching | 4
| Heavy | 5
10 (sensory miscellaneous) | Tender | 1
| Taut | 2
| Rasping | 3
| Splitting | 4
11 (tension) | Tiring | 1
| Exhausting | 2
| Sickening | 1
| Suffocating | 2
14 (punishment) | punishing | 1
| gruelling | 2
| cruel | 3
| vicious | 4
| killing | 5
15 (affective-evaluative-sensory: miscellaneous) | wretched | 1
| blinding | 2
16 (evaluative) | annoying | 1
| troublesome | 2
| miserable | 3
| intense | 4
| unbearable | 5
17 (sensory: miscellaneous) | spreading | 1
| radiating | 2
| penetrating | 3
| piercing | 4
18 (sensory: miscellaneous) | tight | 1
| numb | 2
| drawing | 3
| squeezing | 4
| tearing | 5
19 (sensory) | cool | 1
| cold | 2
| freezing | 3
20 (affective-evaluative: miscellaneous) | nagging | 1
| nauseating | 2
| agonizing | 3
| dreadful | 4
| torturing | 5

pain score = SUM(points for applicable descriptors)

2 How Does Your Pain Change with Time?

Question | Response | Points
Which word or words would you use to describe the pattern of your pain? | continuous steady constant | 1
| rhythmic periodic intermittent | 2
| brief momentary transient | 3

Do the following items increase or decrease your pain?
1. liquor
2. stimulants such as coffee
3. eating
4. heat
5. cold
6. damp
7. weather changes
8. massage or use of a vibrator
9. pressure
10. no movement
11. movement
12. sleep or rest
13. lying down
14. distraction (TV reading etc.)
15. urination or defecation
16. tension
17. bright lights
18. loud noises
19. going to work
20. intercourse
21. mild exercise
22. fatigue

3 How Strong is Your Pain?

Statement: People agree that the following 5 words (mild discomforting distressing horrible excruciating) represent pain of increasing intensity. To answer each question below write the number of the most appropriate word in the space beside the question.

Question | Response | Points
Which word describes your pain right now? | Mild | 1
| Discomforting | 2
| Distressing | 3
| Horrible | 4
| Excruciating | 5
Which word describes it at its worst? | Mild | 1
| Discomforting | 2
| Distressing | 3
| Horrible | 4
| Excruciating | 5
Which word describes it when it is least? | Mild | 1
| Discomforting | 2
| Distressing | 3
| Horrible | 4
| Excruciating | 5
Which word describes the worst toothache you ever had? | Mild | 1
| Discomforting | 2
| Distressing | 3
| Horrible | 4
| Excruciating | 5
Which word describes the worst headache you ever had? | Mild | 1
| Discomforting | 2
| Distressing | 3
| Horrible | 4
| Excruciating | 5
Which word describes the worst stomach-ache you ever had? | Mild | 1
| Discomforting | 2
| Distressing | 3
| Horrible | 4
| Excruciating | 5

Interpretation:
- Maximum pain score: 78
- The higher the pain score the greater the pain.

References:

Melzack R. The McGill Pain Questionnaire: Major properties and scoring methods. Pain. 1975;1:277-299. [pmid: 1235985].

Stein C, Mendl G. The German counterpart to McGill Pain Questionnaire. Pain. 1988;32:251-255. [pmid: 3362561].

- Minimum pain score: 0 (would not be seen in a person with true pain)

Table 5 Downs and Black Quality Assessment – A 27 item tool

Item | Rating
Reporting
Is the hypothesis/aim/objective of the study clearly described? | Yes / No
Are the main outcomes to be measured clearly described in the Introduction or Methods section? | Yes / No
Are the characteristics of the patients included in the study clearly described? | Yes / No
Are the interventions of interest clearly described? | Yes / No
Are the distributions of principal cofounders in each group of subjects to be compared clearly described? | Yes / No
Are the main findings of the study clearly described? | Yes / No
Does the study provide estimates of the random variability in the data for the main outcome? | Yes / No
Have all the important adverse events that may be a consequence of the intervention been reported? | Yes / No
Have the characteristics of patients lost to follow-ups been described? | Yes / No
Have actual probability values been reported (e.g. 0.035 rather than <0.05) for the main outcomes except where the probability value is less than 0.001? | Yes / No
External validity
Were the subjects asked to participate in the study representative of the entire population from which they were recruited? | Yes / No / Unable to determine
Were those subjects who were prepared to participate representative of the entire population from which they were recruited? | Yes / No / Unable to determine
Were the staff, places and facilities where the patients were treated, representative of the treatment the majority of patients receive? | Yes / No / Unable to determine
Internal validity - bias
Was an attempt made to blind study subjects to the intervention they have received? | Yes / No / Unable to determine
Was an attempt made to blind those measuring the main outcomes of the intervention? | Yes / No / Unable to determine
If any of the results of the study were based on “data dredging”, was this made clear? | Yes / No / Unable to determine
In trials and cohort studies, do the analyses adjust for different lengths of follow-up of patients, or in case-control studies, is the time period between intervention and outcome the same for cases and control? | Yes / No / Unable to determine
Were the statistical tests used to assess the main outcomes appropriate? | Yes / No / Unable to determine
Was compliance with the intervention/s reliable? | Yes / No / Unable to determine
Were the main outcome measures used accurate (valid and reliable)? | Yes / No / Unable to determine
Internal validity – confounding (selection bias)
Were the patients in different intervention groups (trials and cohort studies) or were the cases and controls (case-control studies) recruited from the same population? | Yes / No / Unable to determine
Were study subjects in different intervention groups (trials and cohort studies) or were the cases and controls (case-control studies) recruited over the same period of time? | Yes / No / Unable to determine
Were study subjects randomized to intervention groups? | Yes / No / Unable to determine
Was the randomized intervention assignment concealed from both patients and health care staff until recruitment was complete and irrevocable? | Yes / No / Unable to determine
Was there adequate adjustment for confounding in the analyses from which the main findings were drawn? | Yes / No / Unable to determine
Were loses of patients to follow-up taken into account? | Yes / No / Unable to determine
Power
Did the study have sufficient power to detect a clinically important effect where the probability value for a difference being due to chance is less than 5%? | Yes / No