# Peer Reviewers & Technical Expert Panel

The UO-EPC gratefully acknowledges the following individuals who served on our Technical Expert Panel (TEP). Acknowledgment does not reflect endorsement of this report.

Dr. Jill Hayden, D.C, PhD

Community Health & Epidemiology

Dalhousie University

Halifax, NS

Dr. Gert Bronfort, D.C, PhD

Vice President of Research

Northwestern Health Sciences University

Bloomington, MN

Dr. Karen Sherman MPH, PhD

Senior Investigator

Group Health Research Institute

Seattle, WA

Dr. Rick Deyo, M.D., M.P.H.

Department of Family Medicine

Oregon Health & Science University

Portland, OR

The UO-EPC gratefully acknowledges the following individuals who peer reviewed the initial draft of this report. Acknowledgment does not reflect endorsement of this report.

Dr. Gert Bronfort, D.C, PhD

Vice President of Research

Northwestern Health Sciences University

Bloomington, MN

Dr. Jeanette Ezzo, MPH, PhD

Director of Research

JPS Enterprises

Baltimore, MD

Dr. Christine Goertz, DC, PhD

Vice Chancellor for Research & Health Policy

Palmer Center for Chiropractic Research

Davenport, IA

Dr. Roger Chou, MD

Associate Professor of Medicine

Oregon Health & Science University

Portland, OR

Dr. Andrew Vickers, PhD

Research Methodoligist & Biostatistician

Memorial Sloan – Kettering Cancer

Center New York, NY

Dr. Timothy Flynn, PhD

Associate Professor

Regis University

Denver, CO

Dr. Lixing Lao, MD, PhD

Director, TCM Research Program

Centre for Integrative Medicine

University of Maryland

Baltimore, MD

Dr. Christopher Moyer, PhD

Assistant Professor

Department of Psychology

University of Wisconsin-Stout

Menomonee, WI