# List of Excluded Studies

## Non-RCT; 1- Not a Comparative Study of CAM Intervention

Vertebralisdissektion nach chirotherapeutischer Deblockierung nach Halswirbelsaulenbeschwerden. Aktuelles Urteil des LG Duisberg vom 28. Juni 2001. Manuelle Medizin. 2001;39(5):282-286.
Adverse effects of chiropractic. Focus on Alternative and Complementary Therapies. Dec. 2005;10(4):331. (1 ref) 2005;(4):331.
Austin R T. Pathological vertebral fractures after spinal manipulation. Br Med J (Clin Res). 1985;291(6502):1114-1115.
Barker M E. Spinal manipulation. A general practice study. Manuelle Medizin. 1995;33(6):173-175.
Boesler D, Warner M, Alpers A, et al. Efficacy of high-velocity low-amplitude manipulative technique in subjects with low-back pain during menstrual cramping. Journal of the American Osteopathic Association. 1993;93(2):203-208+213. [pmid: 8432669].
Bronfort G. Chiropractic treatment of low back pain: a prospective survey. Journal of Manipulative & Physiological Therapeutics. 1986;9(2):99-113. [pmid: 2942620].
Cerimagic D, Glavic J, Lovrencic-Huzjan A, et al. Occlusion of vertebral artery, cerebellar infarction and obstructive hydrocephalus following cervical spine manipulation [2]. European Neurology. 2007;58(4):248-250. [pmid: 17851248].
Corcoll J, Orfila J, Tobajas P, et al. Implementation of neuroreflexotherapy for subacute and chronic neck and back pain within the Spanish public health system: Audit results after one year. Health Policy. 2006;79(2-3):345-357. [pmid: 16563551].
Davis C. Chiropractic for low back pain - Professor of Uncomplementary Medicine?. British Journal of Chiropractic. 1999;3(1):3.
Ernst E. The safety of chiropractic cervical manipulation. Focus on Alternative and Complementary Therapies. 2008;13(1):41.
Fattori B, Ursino F, Cingolani C, et al. Acupuncture treatment of whiplash injury. International Tinnitus Journal. 2004;10(2):156-160. [pmid: 15732514].
Galm R, Frohling M, Rittmeister M, et al. Sacroiliac joint dysfunction in patients with imaging-proven lumbar disc herniation. European Spine Journal. 1998;7(6):450-453. [pmid: 9883953].
Hooper J. Low back pain and manipulation. Paraparesis after treatment of low back pain by physical methods. Medical Journal of Australia. 1973;1(11):549-551. [pmid: 4266988].
Horton S J. Acute locked thoracic spine: treatment with a modified SNAG. Manual Therapy. 2002;7(MAY):103-107. [pmid: 12151247].
Kinalski R, Kuwik W, Pietrzak. The comparison of the results of manual therapy versus physiotherapy methods used in treatment of patients with low back pain syndromes. Journal Manual Medicine. 1989;4(2):44-46.
Lanska D J, Lanska M J, Fenstermaker R, et al. Thoracic disk herniation associated with chiropractic spinal manipulation. Archives of Neurology. 1987;44(10):996-997. [pmid: 3632387].
Leboeuf-Yde C, Gronstvedt A, Borge J A, et al. The Nordic Back Pain Subpopulation Program: demographic and clinical predictors for outcome in patients receiving chiropractic treatment for persistent low-back pain. Journal of Manipulative and Physiological Therapeutics. 2004;27(8):493-502. [pmid: 15510092].
Lee J H, Lo J. Acupuncture in treatment of chronic pain and post-lumbar puncture headache. One year's experience. Minnesota Medicine. 1978;61(7):429-430. [pmid: 672868].
Livingston M C. Spinal manipulation causing injury. A three-year study. Clinical Orthopaedics & Related Research. 1971;81:82-6. 1971 Nov-Dec.82-86. [pmid: 4257238].
Lovacky S, Lodin Z, Tauber O, et al. Acupuncture treatment and its effect on low back pain: correlation with beta-endorphin immunoreactivity (BEI). American Journal of Acupuncture. 1987;15(3).
Macdonald R, Bell C. Osteopathic manipulation on trial in low back pain. Manual Medicine. 1989;4(3):102.
Marback N. Complications in a low back case. ACA Journal of Chiropractic. 1980;17(DEC):S131-S134.
Mierau D, Cassidy J D, McGregor M, et al. A comparison of the effectiveness of spinal manipulative therapy for low back pain patients with and without spondylolisthesis. Journal of Manipulative & Physiological Therapeutics. 1987;10(2):49-55. [pmid: 2953840].
Moraska A, Chandler C. Changes in Clinical Parameters in Patients with Tension-type Headache Following Massage Therapy: A Pilot Study. The Journal of Manual & Manipulative Therapy. 2008;(16):106-112. 106-112.
Norris J W, Beletsky V, Nadareishvili Z G. Sudden neck movement and cervical artery dissection. Orthopaedic Division Review. 2003;2003(2):26-28.
Odsberg A, Schill U, Haker E. Acupuncture treatment: Side effects and complications reported by Swedish physiotherapists. Complementary Therapies in Medicine. 2001;9(1):17-20. [pmid: 11264965].
Owen J, Green B N. Clinical and quality of life changes in a patient with cervical spinal stenosis following chiropractic and homeopathic care. Alternative Therapies in Health & Medicine. 2004;10(3):74-76. [pmid: 15154156].
Plaugher G, Kokjohn K. The effect of spinal manipulation on pain and prostaglandin levels in women with primary dysmenorrhea [6]. Journal of Manipulative and Physiological Therapeutics. 1993;16(3):199-201. [pmid: 8192720].
Pollard H, Thompson P, Tuchin P. Effect of chiropractic manipulation on chronic neck pain in women aged between 30 and 40 years of age. European Journal of Chiropractic. 2002;49(2):182.
Powell F, Hanigan W, Olivero W. A Risk\Benefit Analysis of Spinal Manipulation Therapy for Relief of Lumbar or Cervical Pain. Neurosurgery. JUL. 1993;33(1):73-79. [pmid: 8355850].
Rico R C, Trudnowski R J. Studies with electro-acupuncture. Journal of Medicine. 1982;13(3):247-251. [pmid: 6217269].
Rowell R M, Polipnick J. A pilot mixed methods study of patient satisfaction with chiropractic care for back pain. Journal of Manipulative & Physiological Therapeutics. 2008;31(8):602-610. [pmid: 18984243].
Rubinstein S M, Knol D L, Leboeuf-Yde C, et al. Benign adverse events following chiropractic care for neck pain are associated with worse short-term outcomes but not worse outcomes at three months. Spine. 2008;33(25):E950-E956. [pmid: 19050572].
Rubinstein S M, Knol D L, Leboeuf-Yde C, et al. Predictors of a favorable outcome in patients treated by chiropractors for neck pain. Spine. 2008;33(13):1451-1458. [pmid: 18520940].
Rubinstein S M, Leboeuf-Yde C, Knol D L, et al. Predictors of adverse events following chiropractic care for patients with neck pain. Journal of Manipulative & Physiological Therapeutics. 2008;31(2):94-103. [pmid: 18328935].
Schmitt H P. [Manual therapy in the region of the cervical spine. Manual therapy of the cervical spine and its dangers: ruptures and occlusions of the vertebral artery]. [German]. ZFA.- Zeitschrift fur Allgemeinmedizin. 1978;54(8):467-474. [pmid: 636540].
Shaw T W. Chiropractic rehabilitation of the retraumatized postsurgical lumbar spine with radiculopathy. Chiropractic. 1994;9(4):108-111.
Smith M, Stano M. Costs and recurrences of chiropractic and medical episodes of low-back care. Journal of Manipulative & Physiological Therapeutics. 1997;20(1):5-12. [pmid: 9004117].
Stano M, Haas M, Goldberg B, et al. Chiropractic and medical care costs of low back care: results from a practice-based observational study. American Journal of Managed Care. 2002;8(9):802-809. [pmid: 12234021].
Tobis JS, Hoehler FK. Musculoskeletal manipulation in the treatment of low back pain. Bulletin New York Academic Medicine. 1983;59(7):660-668.
Triano J J, Gudavalli S, Seals M, et al. Confounded Association: Cervical spine manipulation and adverse cerebrovascular events. The Journal of Chiropractic Education. 2005;19(SPR):37.
White A. Acupuncture for repetitive strain caused side effects, and no benefit. Acupuncture in Medicine. 2008;26(2):126.
Wilson E, Payton O, Donegan-Shoaf L, et al. Muscle energy technique in patients with acute low back pain: a pilot clinical trial. Journal of Orthopaedic & Sports Physical Therapy. 2003;33(9):502-512. [pmid: 14524509].
YeLverton C, Palmer M. Chiropractic treatment to improve the quality of life for patients with ankylosing spondylitis. European Journal of Chiropractic. 2002;49(2):200-201.
Yochum T R, Maola C J. Schmorl's node phenomenon. American Chiropractor. 2003;25(2):14-15.

## Non-RCT: 2- Observational (Comparative) Study not Reporting Harms

Chu J. Dry needling (intramuscular stimulation) in myofascial pain related to lumbosacral radiculopathy. European Journal of Physical Medicine and Rehabilitation. 1995;5(4):106-121.
Coxhead C E. A clinical trial of the management of sciatica with or without low back pain. Physiotherapy. 1974;60(3):72-74. [pmid: 4445302].
Coyer A B, Curwen IHM. Low back pain treated by manipulation: a controlled series. British Medical Journal. 1955;19(March):705-707. [pmid: 14351753].
Ernst E. Traditional acupuncture for reflex sympathetic dystrophy: a randomized, sham controlled, double blind trial. Acupunct Med. 1995;13(2):78-80.
Fox EJ, Melzack. Transcutaneous electrical stimulation and acupuncture: comparison of treatment for low-back pain. Pain. 1976;2(2):141-148. [pmid: 141018].
Grieves B, Menke J M, Pursel K J. Cost Minimization Analysis of Low Back Pain Claims Data for Chiropractic Vs Medicine in a Managed Care Organization. Journal of Manipulative and Physiological Therapeutics. 2009;32(9):734-739. Date of Publication: November 2009/December 2009. 2009;(9):734-739. [pmid: 20004800].
Haas M, Goldberg B, Aickin M, et al. A practice-based study of patients with acute and chronic low back pain attending primary care and chiropractic physicians: two-week to 48-month follow-up. Journal of Manipulative & Physiological Therapeutics. 2004;27(3):160-169. [pmid: 15129198].
Hamre H J, Witt C M, Glockmann A, et al. Anthroposophic vs. conventional therapy for chronic low back pain: a prospective comparative study. European Journal of Medical Research. 2007;12(7):302-310. [pmid: 17933703].
Hansen B U, Olofsson Y, Strombeck B, et al. Periostal acupuncture in patients with rheumatoid arthritis and chronic neck-pain. Scandinavian Journal of Rheumatology. Supplement. 1992;9310.
Hansen J A. A comparative study of two methods of acupuncture treatment for neck and shoulder pain. Acupuncture in Medicine. 1997;15(2):71-73.
Harrison D E, Cailliet R, Harrison D D, et al. A new 3-point bending traction method for restoring cervical lordosis and cervical manipulation: a nonrandomized clinical controlled trial. Archives of Physical Medicine & Rehabilitation. 2002;83(4):447-453. [pmid: 11932844].
Hurwitz E L. The relative impact of chiropractic vs. medical management of low back pain on health status in a multispecialty group practice. Journal of Manipulative & Physiological Therapeutics. 1994;17(2):74-82. [pmid: 8169546].
Laitinen J. Acupuncture and transcutaneous electric stimulation in the treatment of chronic sacrolumbalgia and ischialgia. American Journal Chinese Medicine. 1976;4(2):169-175.
Liu L-M, Zhu C-X, Cheng Z-S. Effect of maneuver treatment on cervical pain point on tension headache. Chinese Journal of Clinical Rehabilitation. 2004;8(17):3418-3419.
Lu X I N H. [Analysis on treatment of sciatica by acupuncture]. Shanghai journal of acupuncture and moxibustion. 1998;17(2):25-26.
Melancon B, Miller L H. Massage therapy versus traditional therapy for low back pain relief: implications for holistic nursing practice. Holistic Nursing Practice. 2005;19(3):116-121. [pmid: 15923937].
Melchart D, Streng A, Reitmayr S, et al. Program for the evaluation of patient care with acupuncture (PEP-AC) - Scientific assistance of the trial phases of German social health insurance companies. [German]. Zeitschrift fur Arztliche Fortbildung und Qualitatssicherung. 2004;98(6):471-473. [pmid: 15527188].
Ossendorf A, Schulte E, Hermann K, et al. Use of complementary medicine in patients with chronic pain. European Journal of Integrative Medicine. 2009;1(2):93-98. Date of Publication: July 2009. 2009;(2):93-98.
Prady S L, Thomas K, Esmonde L, et al. The natural history of back pain after a randomised controlled trial of acupuncture vs usual care--long term outcomes. Acupuncture in Medicine. 2007;25(4):121-129. [pmid: 18160922].
Riikonen A. Acupuncture and proquazone in the treatment of chronic pain in the neck and shoulder region. Acupuncture & electro therapeutics research. 1985:228-230.
Rogers R G. The effects of spinal manipulation on cervical kinesthesia in patients with chronic neck pain: a pilot study. Journal of Manipulative & Physiological Therapeutics. 1997;20(2):80-85. [pmid: 9046455].
Sawazaki K, Mukaino Y, Kinoshita F, et al. Acupuncture can reduce perceived pain, mood disturbances and medical expenses related to low back pain among factory employees. Industrial.Health. 2008;46(4):336-340. [pmid: 18716381].
Strauss S. Acupuncture therapy in the treatment of chronic head, neck and neck-related pain. Journal of Traditional Chinese Medicine. 1985;5(1):13-18. [pmid: 3849622].
van Tulder M W, Irnich D. [Acupuncture for back pain]. [German]. Forschende Komplementarmedizin. 1999;6(3):154-157. [pmid: 10490339].
van der V, Hogg-Johnson S, Bayoumi A M, et al. Identifying the Best Treatment Among Common Nonsurgical Neck Pain Treatments. A Decision Analysis. Journal of Manipulative and Physiological Therapeutics. 2 SUPPL. 2009;32:S209-S218. [pmid: 19251067].
Von Mencke M. Akupunktur des Schulter Arm Syndroms und der Lumbagie/Ischialgie zwei prosepktive Doppelblind Studien* (Teil II). Akupunktur. 1989:55-13.
Wang J X. [492 cases of lumbar pain treated by acupuncture] (in Chinese). [Shanghai Journal of Acupuncture and Moxibustion]. 1996;15(5):28.
Wehling P. Natural substances and acupuncture against sciatic pain. [German]. Akupunktur. 1997;25(2):160-161.
Yeh H-Y, Chen Y-C, Chen F-P, et al. Use of traditional Chinese medicine among pregnant women in Taiwan. International Journal of Gynecology and Obstetrics. 2009;107(2):147-150. Date of Publication: November 2009. 2009;(2):147-150. [pmid: 19716133].

## Narrative Review, Non Relevant SR, Letter to Editor, or Commentary

Summaries for patients. Acupuncture for the treatment of low back pain. [original report in Ann Intern Med. 2005 Apr 19;142(8):635-50; PMID: 15838071]. Annals of Internal Medicine. 2005;142(8):I76. 2005. [pmid: 15838064].
Summaries for patients. Acupuncture for treatment of chronic neck pain. [original report in Ann Intern Med. 2004 Dec 21;141(12):911-9; PMID: 15611488]. Annals of Internal Medicine. 2004;141(12):I26. 2004.
Low back pain: comparison of chiropractic and hospital outpatient treatment. [comment]. BMJ. 1990;301(6747):341-342. [pmid: 2144196].
Comparison of chiropractic and hospital outpatient management of low back pain: a feasibility study. Report of a working group. Journal of Epidemiology & Community Health. 1986;40(1):12-17. [pmid: 2872260].
Acupuncture for pain and dysfunction after neck dissection: Preliminary of a randomized controlled trial. Journal of Supportive.Oncology. 2008;6(6):295-296.
Longterm specific effect of acupuncture on chronic neck pain (n=24). Acupuncture in Medicine. 2004;22(3):161-162.
Acupuncture is effective for chronic LBP in older patients (n=55). Acupuncture in Medicine. 2004;22(3):161.
Acupuncture. Medical Letter on Drugs and Therapeutics. 2006;48(1234):38-39. [pmid: 16685246].
Spinal manipulation. Medical Letter on Drugs and Therapeutics. 2002;44(1131):50. [pmid: 12045754].
Robin Goodfellow. Rheumatology. 2002;41(2):238. [pmid: 11886983].
Minerva. British Medical Journal. 1991;303(6795):198.
Complementary therapy costly and of limited benefit. Pharmaceutical Journal. 2005;275(7372):506.
Acupuncture. Focus on Alternative and Complementary Therapies. 2008;13(2):127-128.
POEMS: patient-oriented evidence that matters. Acupuncture is effective for long-term back pain relief. Journal of the American Academy of Physician Assistants. 2007;20(1):54.
Acupuncture superior to sham-acupuncture and to no treatment for patients with chronic back pain. BackLetter. 2005;20(5):52-53.
POEMs: patient-oriented evidence that matters. [Commentary on] Acupuncture effective for chronic back pain. JAAPA/Journal of the American Academy of Physician Assistants. Aug. 2005;18(8):61. 2005;18(8):61.
Acupuncture superior to sham-acupuncture and to no treatment for patients with chronic back pain. Bone & Joint. 2005;11(7):79-81.
Chronic neck pain: is acupuncture simply a more effective placebo than massage?. Joint Letter. 2001;7(8):87.
Researchers to study acupuncture for low back pain. Acupuncture Today. Mar. 2000;1(3):1. 19. (5 ref) 2000;13(3):1, 19.
Acupuncture and massage for neck pain: confusing results. BackLetter. 2001;16(8):87.
For low back pain, chiropractic care and McKenzie-style PT only slightly better than one-dollar booklet. Joint Letter. 1998;4(9):97-103. 104.
Massage surprisingly effective for chronic back pain: acupuncture and education comparatively ineffective in new randomized trial. Joint Letter. Jan. 1999;5(1):3. (1 ref) 1999;(1):3.
Acupuncture not effective for relieving low back pain: proof for other musculoskeletal conditions uneven. Joint Letter. Jul-Aug. 1999;5(7):77. (2 ref) 1999;(7):77.
Newscaps. American Journal of Nursing. 2008;108(3):22.
Chiropractic management of hypertension: new trial provides convincing evidence of effectiveness. Chiropractic Report. May. 2007;21(3):1-3. 6. 8. (13 ref) 2007;(3):1-3.
Acupuncture. Focus on Alternative and Complementary Therapies. Sep. 2006;11(3):244-6. 2006;(3):244-246.
Studies connect patient satisfaction with back pain outcomes. Journal of Pain & Palliative Care Pharmacotherapy. 2007;21(1):116-7. 2007;21(1):116-117.
Acupuncture. Focus on Alternative and Complementary Therapies. Sep. 2007;12(3):213-6. 2007;(3):213-216.
California study confirms cost-effectiveness. Chiropractic Report. Nov. 2004;18(6):1-3. 6. 8. (16 ref) 2004;(6):1-3.
Study shows manipulation-exercise combination more effective for back pain: but “manipulation alone probably gives better value for money”. Dynamic Chiropractic. Jan. 1. 2005;23(1):1-45. (3 ref) 2005;23(1):1.
Chiropractic management of back pain: a treatment that stands up. Chiropractic Report. Jul. 2003;17(4):1-8. (43 ref) 2003;(4):1-8.
Reinforcing the value of massage for back pain: Annals of Internal Medicine report: massage is a successful, cost-effective treatment. Massage Today. 2003;3(7):1.
Exercise programs -- do they really work?. Chiropractic Report. Nov. 1997;11(6):1-8. (24 ref) 1997;11(6):1-8.
Manual,Therapy. Cochrane. 2002;(3):131-149.
The cost of CAM for back pain. Focus on Alternative and Complementary Therapies. Dec. 2005. 2005;327.
Chiropractic Effective for Cervicogenic Headache. Dynamic Chiropractic. 1997;15(22). OCT.
Manual Therapy for Neck Pain Favored over PT & GP Care, Study Says. Dynamic Chiropractic. 2002;20(14). JUL.
Chiropractic Best for Chronic Spine Pain. Dynamic Chiropractic. 2003;21(19). SEP.
Other Headaches and Pain. Headache. NOV. 2003;43(10):1126-1127.
Answer to the letter to the editor of J. Hebert et al. concerning, 'Hancock MJ, Maher CG, Latimer J, Herbert RD, McAuley JH (2008) Independent evaluation of a clinical prediction rule for spinal manipulative therapy: a randomised controlled trial. Epub ahead of publication DOI:10.1007/s00586-008-0679-9'. European Spine Journal. 2008;17(10):1403-1404.
Letter to the editor concerning 'Independent evaluation of a clinical prediction rule for spinal manipulative therapy: a randomised controlled trial' (M. Hancock et al.). European Spine Journal. 2008;17(10):1401-1402. [pmid: 18751743].
I have arthritis-related neck pain. Can non-surgical spinal decompression with cold-laser therapy bring some relief?. DukeMedicine healthnews. 2009;15(9):8. Date of Publication: Sep 2009. 2009;(9):8.
Abe H, Imamura H. [Diagnosis and therapy in patients with headache due to neck lesions]. [Japanese]. Nippon Naika Gakkai Zasshi - Journal of Japanese Society of Internal Medicine. 1993;82(1):82-86.
Abernethy A P. Randomized controlled trial of acupuncture for chronic neck pain. Journal of Pain & Palliative.Care Pharmacotherapy. 2008;(1):25-26.
Altafini L, Ceccherelli F, Avila A, et al. Reflexotherapy in patients suffering from myofascial pain due to cervical arthrosis - Double blind study of two techniques. [German]. Deutsche Zeitschrift fur Akupunktur. 1989;32(4):74-82.
Ammer K, Rathkolb O. Physical therapy in occipital headaches. Manual Medizin. 2000;28(4):65-68.
Anon. Chiropractic in the literature... commentary on “Overview of chronic spinal pain syndrome: a clinical pilot trial comparing acupuncture, a nonsteroidal anti-inflammatory drug, and spinal manipulation”. J Manipulative Physiol Ther. 1999;22(6):376-381. Giles, LGF, Muller R. Journal of the American Chiropractic Association 2000;37(3):38. [pmid: 10478769].
Anzalone G A. These findings reinforce an important point... Frequency and clinical predictors of adverse reactions to chiropractic care in the UCLA neck pain study. Hurwitz E, Morgenstern H, Vassilaki M, et al., editors. Spine. July. 1. 2005;30(13):1477-84. Dynamic Chiropractic.2005 Oct 24; 23(22): 34, 37, 42.(4 ref) 2005;(22):34. [pmid: 15990659].
Aspegren D, Akuthota V, Tyburski M, et al. Chiropractic Treatment of a Patient with Progressive Lumbar Disk Injury, Spondylolisthesis, and Spondyloptosis. Journal of Manipulative and Physiological Therapeutics. 2006;29(8):686. [pmid: 17045104].
Assendelft W J, Bouter L M, Kessels A G. Wirksamkeit von Chiro- und Physiotherapie bei lumbalen Ruckenschmerzen: eine kritische Diskussion der britischen randomisierten klinischen Studie. Manuelle Medizin. 1993;31(2):34-38.
Bai W J, Tan J L. [Observation on therapeutic effects of centro-square needling and triple needling on ankylosing spondylitis]. [Chinese]. Zhongguo Zhenjiu. 2006;26(7):495-497.
Bakker E W, Verhagen A P, van Trijffel E, et al. Individual advice in addition to standard guideline care in patients with acute non-specific low back pain: a survey on feasibility among physiotherapists and patients. Manual Therapy. 2009;14(1):68-74. [pmid: 18165146].
Baldry P. Comparison of Superficial and Deep Acupuncture in the Treatment of Lumbar Myofascial Pain. Journal of Musculoskeletal Pain. 2003;11(2):61-62.
Balestra L. [Preliminary experiences with treatment of pain by use of acupuncture]. [Italian]. Minerva Medica. 1979;70(24):1717-1720. [pmid: 450310].
Baquie P. An investigation into the potential relationship between inter-vertebral joint hypermobility and pain response in ballet dancers suffering lower back pain [abstract]. Aust J Physiother. 1986;32(3):204-205.
Barker M. Spinal Manipulation: A General Practice Study. Journal of Orthopaedic Medicine. 1994;16(2):42-44.
Barlas P, Goddard G, Shen Y. Being statistically significant is like being pregnant: you either are or you are not; effects of acupuncture on myofascial pain still obscure. Focus on Alternative and Complementary Therapies. Mar. 2008;13(1):38-40. (8 ref) 2008;(1):38-40.
Bartelsman M. Patients with non-specific low back pain might benefit from acupuncture. [Dutch]. Nederlands Tijdschrift voor Geneeskunde. 2007;151(21):1205.
Bassano J. Science of chiropractic. Lumbar spine: old vs. new compression fracture. Dynamic Chiropractic. Jan. 29. 2006;24(3):24. 30. (4 ref) 2006;(3):24.
Baxter G D. Laser acupuncture for whiplash: what have we learned about dosages (and placebo)?. Focus on Alternative and Complementary Therapies. Dec. 2006;11(4):311-2. (4 ref) 2006;(4):311-312.
Baxter G D. Acupressure: a role in the management of chronic low back pain?. Focus on Alternative and Complementary Therapies. Sep. 2006;11(3):217-8. (3 ref) 2006;(3):217-218.
Baxter G D, Kerr D P, Walsh D M. Acupuncture in the management of chronic low back pain: a blinded randomized controlled trial. Focus on Alternative and Complementary Therapies. MAR. 2001;6(1):70-71.
Blomberg S, Svardsudd K, Tibblin G. Manual therapy with steroid injections in low-back pain. Improvement of quality of life in a controlled trial with four months' follow-up. Scandinavian Journal of Primary Health Care. 1993;11(2):83-90. [pmid: 8356370].
Boezaart A P, Eksteen J A, Spuy G V, et al. A controlled, mulitcentre trial of manual therapy with steroid injections in low-back pain: functional variables, side effects and complications during four months follow-up. Spine. 1999;24(11):1131-1137. [pmid: 10361663].
Bogduk N. Spinal manipulation for neck pain does not work. [see comment]. Journal of Pain. 2003;4(8):427-428. [pmid: 14622661].
Bogduk N. Headaches and cervical manipulation. Medical Journal of Australia. 1979;2(2):65-66. [pmid: 492025].
Bogduk N. Manual therapy produces greater relief of neck pain than physiotherapy or general practitioner care. Australian Journal of Physiotherapy. 2002;48(3):240. [pmid: 12369567].
Bowsher D, Mumford J, Lipton S, et al. Treatment of intractable pain by acupuncture. Lancet. 1973;2(7820):57-60. [pmid: 4123617].
Boylan M. Massage found to be best non-drug treatment in spinal cord injuries pain. Journal of the Australian Traditional-Medicine Society. Jun. 2005;11(2):75. 95. 1995;(2):75.
Braakman R. [Whiplash]. [Dutch]. Nederlands Tijdschrift voor Geneeskunde. 1976;120(39):1634-1640. [pmid: 980128].
Breen A. Manipulation of the neck and stroke: Time for more rigorous evidence. Medical Journal of Australia. 2002;176(8):364-365. [pmid: 12041629].
Brennan P C, Graham M A, Triano J J, et al. Lymphocyte profiles in patients with chronic low back pain enrolled in a clinical trial. Journal of Manipulative & Physiological Therapeutics. 1994;17(4):219-227. [pmid: 8046277].
Brien P, Brien M J, Budd K, et al. Low back pain [1]. British Medical Journal. 1995;311(7004):568-569. [pmid: 7663219].
Brodin H. Inhibition-Facilitation Technique for Lumbar Pain Treatment. International Journal of Rehabilitation Research. 1984;(7):328-329.
Brodke D S, Ritter S M. Nonoperative management of low back pain and lumbar disc degeneration. Journal of Bone and Joint Surgery - Series A. 2004;86(8):1810-1818.
Bronfort G. The initiation of a primary care interdisciplinary controlled clinical trial on low back pain: a report on preliminary findings and doctor compliance problems. Journal of Manipulative and Physiological Therapeutics. FEB. 1990;13(2):120.
Brown A, Angus D, Chen S, et al. Costs and outcomes of chiropractic treatment for low back pain (Structured abstract). Ottawa. Canadian Coordinating Office for Health Technology Assessment (CCOHTA). 2005:88.
Canter P H. Surprise result: Pragmatic trials favour spinal manipulation on psychological outcomes!: Commentary. Focus on Alternative and Complementary Therapies. 2008;13(2):117-118.
Canter P H. Incomplete data render cost comparison of chiropractic with medical care for back pain inconclusive. Focus on Alternative and Complementary Therapies. 2005;10(4):311-312.
Canter P H, Witt C M, Brinkhaus B, et al. Short-term cost-effectiveness study of acupuncture for chronic low back pain: Commentary. Focus on Alternative and Complementary Therapies. 2007;12(1):41-42.
Cao P, Fang Z, Liang Y, et al. [The retrospective analysis of surgical treatment for traumatic instability of sub-axial cervical spine]. [Chinese]. Chung-Hua Wai Ko Tsa Chih. Chinese Journal of Surgery. 2008;46(3):196-199. [pmid: 18683715].
Carrick F. Treatment of pathomechanics of the lumbar spine by manipulation. Journal of Manipulative and Physiological Therapeutics. DEC. 1981;4(4):173-178.
Chen D, Luo L P, Hong Y B, et al. [Controlled study on needle-pricking therapy combined with spinal massage for treatment of ankylosing spondylitis]. [Chinese]. Zhongguo Zhenjiu. 2008;28(3):163-166.
Chen G S, Hwang Y C. Therapeutic effect of acupuncture for chronic pain. American Journal of Chinese Medicine. 1977;5(1):45-61. [pmid: 848456].
Chenot J F, Becker A, Leonhardt C, et al. Use of complementary alternative medicine for low back pain consulting in general practice: a cohort study. BMC Complementary & Alternative Medicine. 2007;7(42). 2007.42, 2007.
Cherkin D C, Sherman K J, Kahn J, et al. Effectiveness of focused structural massage and relaxation massage for chronic low back pain: protocol for a randomized controlled trial. Trials [Electronic Resource]. 2009;1096.
Cleland J A. Spinal manipulation: Risks vs. benefits. Southern Medical Journal. 2007;100(2):132-133. [pmid: 17330679].
Cleland J A, Fritz J M, Childs J D, et al. Comparison of the effectiveness of three manual physical therapy techniques in a subgroup of patients with low back pain who satisfy a clinical prediction rule: study protocol of a randomized clinical trial [NCT00257998]. BMC Musculoskeletal Disorders. 2006;7(11). 2006.11, 2006.
Cole C. Does acupuncture or massage work in people with persistent back pain?. Journal of Family Practice. 2001;50(9):799. 2001. [pmid: 11674914].
Colloca C J, Fuhr A W. Safety in chiropractic practice. Part II: Treatment to the upper neck and the rate of cerebrovascular incidents. [comment]. Journal of Manipulative & Physiological Therapeutics. 1997;20(8):567-568. [pmid: 9345689].
Conijn F J. Hurwitz EL Re:, Morgenstern H, Harber P, et al., editors. A randomized trial of medical care with and without physical therapy and chiropractic care with and without physical modalities for patients with low back pain: 6-month follow-up outcomes from the UCLA low back pain study. Spine. 2002;27:2193-204. [comment]. Spine 2003;28(21):2486-2487. [pmid: 12394892].
Conijn F J. A randomized trial of medical care with and without physical therapy and chiropractic care with and without physical modalities for patients with low back pain: 6-month follow-up outcomes from the UCLA low back pain study. [comment]. Spine. 2003;28(14):1625-1626. [pmid: 12865859].
Conijn F J J. Hurwitz EL To the editor... Re:, Morgenstern H, Harber P, et al., editors. A randomized trial of medical care with and without physical therapy and chiropractic care with and without physical modalities for patients with low back pain: 6-month follow-up outcomes from the UCLA low back pain study. Spine. 2002;27:2193-204. Spine 2003;28(14):1625-1626. [pmid: 12394892].
Corbett M, Sinclair M. Letter: Acu- and pleuro-puncture. New England Journal of Medicine. 1974;290(3):167-168. [pmid: 4271463].
Cox J M. A randomized controlled trial comparing 2 types of spinal manipulation and minimal conservative medical care for adults 55 years and older with subacute or chronic low back pain. Journal of Manipulative & Physiological Therapeutics. 2009;32(7):601. [pmid: 19748413].
Croft A. Spinal rounds. Critical new developments in the safety and efficacy of chiropractic treatment, part I. Dynamic Chiropractic. Jan. 1. 2008;26(1):14. 16. 33. (7 ref) 2008;26(1):14.
Croft A C. Is high-utilization chiropractic treatment efficacious in whiplash? [10]. Archives of Internal Medicine. 2006;166(11):1237-1238. [pmid: 16772258].
Crothers A, Walker B, French S D. Spinal manipulative therapy versus Graston Technique in the treatment of non-specific thoracic spine pain: Design of a randomised controlled trial. Chiropractic and Osteopathy. 2008;16. 2008. Article Number: 12. Date of Publication: 30 Oct 2008.
Cummings M. Acupuncture appears to be cost-effective in chronic neck pain: Commentary. Focus on Alternative and Complementary Therapies. 2007;12(1):36-37.
Cummings M. Option of acupuncture for back pain (n=241). Acupuncture in Medicine. 2005;23(3):149-150.
Cummings M. Acupuncture is superior to invasive sham in chronic low back pain (n=174). Acupuncture in Medicine. Jun. 2003;21(1/2):55-6. 2003;21(1/2):55-56.
Cummings M. Acupuncture for pain management before and after lumbar disc protrusion surgery... commentary on Wang RR, Tronnier V. Effect of acupuncture on pain management in patients before and after lumbar disc protrusion surgery -- a randomized control study. Am J Chin Med. 2000;28:25-33. Acupuncture in Medicine.2000 Dec; 18(2): 135. 2000;18(2):135. [pmid: 10794114].
Cummings M. Acupuncture for chronic low back pain (n=60). Acupunct Med. 2004;22(1):53-53.
Cummings M. Deep needle insertion is superior to 2mm insertion in lumbar myofascial pain (n=42). Acupunct Med. 2003;21(2-Jan):57-58.
Cummings M. Formula acupuncture in chronic low back pain. Acupunct Med. 2002;20(3-Feb):126-127.
Cummings M. Therapeutic massage is claimed to be effective for persistent low back pain (n=262). Acupunct Med. 2001;19(1):50-50.
Dabbert O, Freeman D G, Weis A J. Spinal meningeal hematoma, warfarin therapy, and chiropractic adjustment. JAMA. 1970;214(11):2058. 1970. [pmid: 5536482].
Dabbs V, Lauretti W J. A Risk Assessment of Cervical Manipulation vs. NSAIDS For The Treatment of Neck Pain. J Manipulative Physiol Ther. 1995;18(8):530-536. [pmid: 8583176].
Dagenais S, Moher D. Hurwitz EL Re:, Morgenstern H, Vassilaki M, Chiang LM, editors. Frequency and clinical predictors of adverse reactions to chiropractic care in the UCLA neck pain study. Spine. 2005;30:1477-84. [comment]. Spine 2006;31(2):253-254. [pmid: 15990659].
De Hertogh W J, Vaes P H, Devroey D, et al. Management of headache disorders: design of a randomised clinical trial screening for prognostic patient characteristics. BMC Musculoskeletal Disorders. 2007;8(38). 2007.38, 2007.
Denegar C R, Hertel J, Miller S J. Electrotherapy and manual therapy in the treatment of myofascial pain syndrome. Athletic Therapy Today. Nov. 1998;3(6):20-4. 28. 9. 55.(11 ref) 1998;(6): 20-24.
Desmoulin G T, Yasin N I, Chen D W. Spinal mechanisms of pain control. Clinical Journal of Pain. 2007;23(7):576-585. [pmid: 17710007].
Devitt M. Study: acupuncture better than massage for chronic neck pain: researchers find “clear clinical advantages” in reducing pain and improving motion. Acupuncture Today. Sep. 2001;2(9):1. 10. 1910;(9):1.
Devitt M. Study: flexion-distraction effective for chronic LBP. Dynamic Chiropractic. Jun. 6. 2006;24(12):1. 18. 46.(2 ref) 2006;(12):1.
Devitt M. Acupuncture Provides Long-Term Relief of Low Back Pain. Acupuncture Today. 2002;3(3). MAR.
Diener H C. Diclofenac or spinal manipulative therapy are not more effective than standard therapy for acute low back pain. [German]. Arzneimitteltherapie. 2008;26(6):222.
Diener H C, Kramer J, Wippermann F, et al. German acupuncture trials. [German]. Zeitschrift fur Arztliche Fortbildung und Qualitatssicherung. 2004;98(6):468-471. [pmid: 15527187].
Diener H-C. Paracetamol is sufficient for acute low back pain. [German]. MMW-Fortschritte der Medizin. 2008;150(22):23.
Drevet J G, Mezin P, Stoebner P, et al. Ultrasonography investigations in back pains of muscular origin. [French]. Annales de Readaptation et de Medecine Physique. 1989;32(4):409-420.
Dyer C. Should We Be Manipulating Prolapsed Intervertebral Discs?. British Osteopathic Journal. 1982;(14):149-150.
Ebrall P S. A blinded randomized clinical trial of manual therapy and physiotherapy for chronic back and neck complaints: physical outcome measures. [comment]. Spine. 1993;18(1):169-170. [pmid: 8434319].
Ebrall P S. A blinded randomized clinical trial of manual therapy and physiotherapy for chronic back and neck complaints physical outcome measures. [comment]. Journal of Manipulative & Physiological Therapeutics. 1992;15(6):406-407. [pmid: 1431625].
Egger B. The initial results of the gerac studies: Acupuncture is more effective than standard therapy in lower back pain and acupuncture is also effective in knee pain. [German]. Akupunktur und Traditionelle. Chinesische Medizin. 2004;32(4):236-243.
Eisenberg D M, Post D E, Hrbek A L, et al. Testing a model of integrative care in an academic health center: results of a pilot study. Altern Ther Health Med. 2006;12(3):47-47.
Ellestad S M, Nagle R V, Boesler D R, et al. Electromyographic and skin resistance responses to osteopathic manipulative treatment for low-back pain. [German]. Manuelle Medizin. 1990;28(1):7-12.
Ellrodt A. Assessing the risks of cervical manipulation for neck pain. [comment]. CMAJ Canadian Medical Association Journal. 2002;166(9):1134-1135.
Elsner G, Nienhaus A, Beck W. [Occupationally-induced degenerative discopathies in the area of the lumbar spine]. [German]. Sozial- und Praventivmedizin. 1997;42(3):144-154. [pmid: 9334086].
Emery P, Lythgoe S. The effect of acupuncture on ankylosing spondylitis. Br.J Rheumatol. 1986;25(1):132-133. [pmid: 3942842].
Enthoven P, Skargren E, Oberg B. Clinical course in patients seeking primary care for back or neck pain: a prospective 5-year follow-up of outcome and health care consumption with subgroup analysis. Spine. 2004;29(21):2458-2465. [pmid: 15507811].
Erickson R J. Abstract of Acupuncture Massage vs Swedish Massage and Individual Exercises vs Group Exercises in Low Back Pain Sufferers - a randomised controlled clinical trial in a 2 x 2 factorial design (Franke,A.). Med Acup. 2003;14(2):56-56.
Ernst E. Acupuncture for chronic mechanical neck pain. [comment]. Annals of Internal Medicine. 2005;142(10):873-874. [pmid: 15897544].
Ernst E. Chiropractic spinal manipulation for back pain. British Journal of Sports Medicine. 2003;37(3):195-196. [pmid: 12782542].
Ernst E. Massage treatment for back pain. British Medical Journal. 2003;326(7389):562-563. [pmid: 12637375].
Ernst E. Adverse effects of spinal manipulation (8). Journal of the Royal Society of Medicine. 2007;100(10):447.
Ernst E. Is naturopathy effective for low back pain?. Focus on Alternative and Complementary Therapies. 2008;13(1):43.
Ernst E. Is acapuncture worth its price?. [German]. MMW-Fortschritte der Medizin. 2006;148(40):26.
Ernst E. The 'smallwood report': Method or madness?. British Journal of General Practice. 2006;56(522):64-65. [pmid: 16438825].
Ernst E. Manual therapy better than physiotherapy or doctors' care for neck pain. Focus on Alternative and Complementary Therapies. 2002;7(4):363-364.
Ernst E. Spinal manipulation superior to placebo in treating mechanical thoracic spine pain. Focus on Alternative and Complementary Therapies. 2002;7(2):150-151.
Ernst E. Disappointing results for spinal manipulation for neck pain. Focus on Alternative and Complementary Therapies. 2002;7(1):21-22.
Ernst E. Massage is superior to acupuncture for chronic low back pain. Focus on Alternative and Complementary Therapies. 2001;6(3):211.
Ernst E. Massage therapy is effective for subacute low-back pain. Focus on Alternative and Complementary Therapies. 2001;6(1):30-31.
Ernst E. Cost-effectiveness of manual therapy for neck pain. Focus on Alternative and Complementary Therapies. Dec. 2003;8(4):438-9. (4):438-439.
Ernst E. Thiel H W Re:, Bolton J E, Docherty S, et al., editors. Safety of chiropractic manipulation of the cervical spine. Spine. 2007;32:2375-8. Spine. 2007 Oct 1;32(21):2375-8; discussion 2379. Spine 2008;33(5):576-577. [pmid: 17906581].
Ernst E. Acupuncture in back pain: Only placebo?. [German]. MMW-Fortschritte der Medizin. 2009;151(47):22. Date of Publication: 19 Nov 2009. 2009;(47):22.
Ernst E, White A R. Acupuncture for back pain: a meta-analysis of randomized controlled trials. Archives of Internal Medicine. 1998;158(20):2235-2241. [pmid: 9818803].
Ernst E, Hurwitz E, Morgenstern H. A comparison of two different chiropractic packages for back pain. Focus on Alternative and Complementary Therapies. Dec. 2002;7(4):366-7. 2002;(4):366-367.
Ernst E, Santilli V, Beghi E, et al. Spinal manipulation is more effective than sham for sciatica. Focus on Alternative and Complementary Therapies. Sep. 2006;11(3):224-5. 2006;(3):224-225.
Ernst E, Tillett R, Tveito T H, et al. United Kingdom back pain exercise and manipulation (UK BEAM) trial [4] (multiple letters). British Medical Journal. 2005;330(7492):673-674. [pmid: 15775010].
Erzurumlu A, Dursun H, Gunduz S, et al. The management of chronic pain at spinal cord injured patients. The comparison of effectiveness amitryptiline and carbamazepine combination and electroacupuncture application. [Turkish]. Journal of Rheumatology and Medical Rehabilitation. 1996;7(3):176-180.
Evans W. Chiropractic care: attempting a risk-benefit analysis. [comment]. American Journal of Public Health. 2003;93(4):522-523. [pmid: 12660182].
Farabaugh R J. Art of chiropractic. Chiropractic care for chronic pain: a new model, part 1. Dynamic Chiropractic. Oct. 8. 2007;25(21):39. 45. 49. 2007;(21):39.
Farham B. Acupuncture and back pain. South African Medical Journal. 2006;96(11):1180.
Feather K. Acupressure Patients Find Relief for Low Back Pain. Acupuncture Today. 2006;7(6).
Fernandez-de-Las-Penas C, onso-Blanco C, Miangolarra J C. Myofascial trigger points in subjects presenting with mechanical neck pain: A blinded, controlled study. Manual Therapy. 2007;12(1):29-33. [pmid: 21882489].
Ferrari R R, Russell A S. How effective are the available treatments for mechanical neck disorder?: Commentary. Nature Clinical Practice Rheumatology. 2007;3(12):692-693.
Fialka V, Preisinger E, Bohler A. Physical diagnosis and physical therapy of whiplash injury [Zur physikalischen Diagnostik und physikalischen Therapie der Distorsio columnae vertebralis cervicalis]. Zeitschrift fuer Physikalische Medizin, Balneologie, Medizinische Klimatologie. 1989:18390-397.
Fitz-Ritson D. Phasic exercises for cervical rehabilitation after “whiplash” trauma. Journal of Manipulative & Physiological Therapeutics. 1995;18(1):21-24. [pmid: 7706955].
Flynn T W, Childs J D, Fritz J M. The audible pop from high-velocity thrust manipulation and outcome in individuals with low back pain. Journal of Manipulative & Physiological Therapeutics. 2006;29(1):40-45. [pmid: 16396728].
Foster N, Vas J. Acupuncture vs. placebo transcutaneous nerve stimulation for chronic neck pain: Commentary. Focus on Alternative and Complementary Therapies. 2007;12(2):113-115.
Fritz J M, Whitman J M, Flynn T W, et al. Factors related to the inability of individuals with low back pain to improve with a spinal manipulation. Phys Ther. 2004;84(2):173-190. [pmid: 14744207].
Fryer G, Carub J, McIver S. The effect of manipulation and mobilisation on pressure pain thresholds in the thoracic spine. Journal of Osterpathic Medicine. 2004;7(APR):8-14.
Garratt A M. Rasch analysis of the Roland Disability Questionnaire. Spine. 2003;28(1):79-84. [pmid: 12544962].
Gatchel R J. Chronic spinal pain: A randomized clinical trial comparing medication, acupuncture, and spinal manipulation - Point of view. Spine. 2003;28(14):1502-1503.
Giles L G. Hurwitz EL Re:, Morgenstern H, Vassilaki M, Chiang L-M, editors. Frequency and clinical predictors of adverse reactions to chiropractic care in the UCLA neck pain study. Spine. 2005;30:1477-84. [comment]. Spine 2006;31(2):250-251. [pmid: 15990659].
Giles L G, Muller R. Chronic spinal pain syndromes: a clinical pilot trial comparing acupuncture, a nonsteroidal anti-inflammatory drug, and spinal manipulation. Journal of the American Chiropractic Association. 2000;37(4):51.
Gmunder R, Kissling R. The efficacy of homoeopathy in the treatment of chronic low back pain compared to standardised physiotherapy. Z Orthop. 2002;(140):503-8. 503-508. [pmid: 12226773].
Goldberg H. Spinal manipulation is appropriate for low back pain: fact or fiction?. Focus on Alternative and Complementary Therapies. 2003;8(1):14-18.
Good C J, Mikkelsen G B. Intersegmental sagittal motion in the lower cervical spine and discogenic spondylosis: a preliminary study. [see comment]. Journal of Manipulative & Physiological Therapeutics. 1992;15(9):556-564. [pmid: 1469339].
Grant. A randomised comparative trial of acupuncture versus tens for chronic back pain in the elderly. Akupunktur. 1998;26(4):253.
Grier A R. Adverse reactions to chiropractic treatment and their effects on satisfaction and clinical outcomes among patients enrolled in the UCLA Neck Pain Study. [comment]. Journal of Manipulative & Physiological Therapeutics. 2004;27(6):430. Aug. [pmid: 15319768].
Grieve G P. Manipulation therapy for neck pain. Physiotherapy. 1979;65(5):136-146. [pmid: 482424].
Grundy B L, Nash C L, Brown R H. Arterial pressure manipulation alters spinal cord function during correction of scoliosis. Anesthesiology. 1981;54(3):249-253. [pmid: 7469108].
Grunnet-Nilsson N, Bove G. [Therapeutic manipulation of episodic tension type headache. A randomized, controlled clinical trial]. [Danish]. Ugeskrift for Laeger. 2000;162(2):174-177. [pmid: 10647316].
Guthrie R A, Martin R H. Effect of pressure applied to the upper thoracic (placebo) versus lumbar areas (osteopathic manipulative treatment) for inhibition of lumbar myalgia during labor. Journal of the American Osteopathic Association. 1982;82(4):247-251. [pmid: 6218150].
Guzel R, Akkoca H, Seydaoglu G, et al. Efficacy of local anesthetic injection versus dry needling in myofascial pain syndrome treatment. [Turkish]. Turkiye.Fiziksel.Tip.ve.Rehabilitasyon Dergisi. 2006;52(1):22-27.
Haas M, Panzer D, Peterson D, et al. Short-term responsiveness of manual thoracic end-play assessment to spinal manipulation: a randomized controlled trial of construct validity. Journal of Manipulative & Physiological Therapeutics. 1995;18(9):582-589. [pmid: 8775019].
Haas M, Peterson D, Rothman E H, et al. Responsiveness of leg alignment changes associated with articular pressure testing to spinal manipulation: the use of a randomized clinical trial design to evaluate a diagnostic test with a dichotomous outcome. [see comment]. Journal of Manipulative & Physiological Therapeutics. 1993;16(5):306-311. [pmid: 8345313].
Haldeman S, Carroll L, Cassidy J D, et al. The Bone and Joint Decade 2000-2010 Task Force on Neck Pain and Its Associated Disorders. Executive Summary. Journal of Manipulative and Physiological Therapeutics. 2 SUPPL. 2009;32:S7-S9. [pmid: 19251077].
Haneline M T. Safety of chiropractic interventions: a systematic review. Spine. 34(22):2475-2476. (author reply 2476-2477), 2009.Date of Publication: 15 Oct 2009. 2009;(22):2475-2476. [pmid: 19829264].
Haneline M T, Cooperstein R. Hurwitz Re:, et al., editors. Frequency and clinical predictors of adverse reactions to chiropractic care in the UCLA neck pain study. Spine. 2005;30:1477-84. [comment]. Spine 2006;31(2):254-255. [pmid: 15990659].
Hanten W P, Olson S L, Butts N L, et al. Effectiveness of a home program of ischemic pressure followed by sustained stretch for treatment of myofascial trigger points. [see comment]. Physical Therapy. 2000;80(10):997-1003. [pmid: 11002435].
Harman R D, Hawk C. Preliminary study of the effects of a placebo chiropractic treatment with sham adjustments... Preliminary study of the effects of placebo chiropractic treatment with sham adjustments. Hawk C, Azad A, Phongphua C, Long CR, editors. J Manipulative Physiol Ther. 1999;22:436-43. Journal of Manipulative and Physiological Therapeutics. 2000 May; 23(4): 294.(1 ref) 2000;(4):294. [pmid: 10519559].
Harrison D E, Cailliet R, Harrison D D, et al. Changes in sagittal lumbar configuration with a new method of extension traction: nonrandomized clinical controlled trial. Archives of Physical Medicine & Rehabilitation. 2002;83(11):1585-1591. [pmid: 12422330].
Harrison D E, Cailliet R, Harrison D D, et al. Changes in Sagittal Lumbar Configuration with a New Method of Extension Traction Combined with Spinal Manipulation and Its Clinical Significance: Nonrandomized Clinical Control Trial. The Journal of Chiropractic Education. SPR. 2002;16(1):17.
Harter D. Comparison of acupuncture and paravertebral injections in the treatment of lumbosciatica. A retrospective study based upon 253 patients in a pain clinic. [German]. Akupunktur. 1995;23(1):30-36.
Harvey N, Cooper C. Physiotherapy for neck and back pain. British Medical Journal. 2005;330(7482):53-54. [pmid: 15637350].
Hawes M C. Improved chest expansion in idiopathic scoliosis. Psychosomatic Medicine. 2001;63(6):994-995. [pmid: 11719639].
He C Y, Chen W H. Treatment of Lumbar Intervertebral Disc Prolapse with Intravertebral Injection Plus Traction and Massage. Chinese Journal of Traditional Medical Traumatology & Orthopedics. 2003;11(1):16-18.
Herzog W, Symons B, Leonard T R. Forces and elongations of the vertebral artery during range of motion testing, diagnostic procedures and neck manipulative treatments. symposium proceedings of the World Federation of Chiropractic 6th Biennial Congress. Paris, France. 21-26 May 2001. European Journal of Chiropractic. 2002;49(1):79. 2002;(1):79.
Heydenreich A. The economic importance of the aimed reflexotherapy in acute lumbosacral diseases of different aetiology. [German]. Zeitschrift fur Physiotherapie. 1983;35(3):159-165.
Heymans M W, Anema J R, de Vet H C, et al. Does flexion-distraction help treat chronic low back pain?. Nature Clinical Practice Rheumatology. 2006;2(7):360-361.
Hodgson L, Fryer G. The effect of manual pressure release on myofascial trigger points in the upper trapezius muscle. International Journal of Osteopathic Medicine. 2006;9(JUN):33.
Hoiriss K T, Pfleger B, McDuffie F C, et al. Design and implementation of a randomized controlled clinical trial of chiropractic care versus drug therapy for sub-acute low back pain. CRJ: Chiropractic Research Journal. Fall. 1997;4(2):50-63. (61 ref) 1997;(2):50-63.
Holm I. Fusion surgery is slightly better than nonsurgical treatment in patients with severe chronic nonspecific low back pain: Commentary. Australian Journal of Physiotherapy. 2002;48(2):133. [pmid: 12143780].
Hondras M A, Long C R, Brennan P C. Spinal manipulative therapy versus a low force mimic maneuver for women with primary dysmenorrhea: a randomized, observer-blinded, clinical trial. Pain. 1999;81(1-2):105-114. [pmid: 10353498].
Hondras M A, Long C R, Haan A G, et al. Recruitment and enrollment for the simultaneous conduct of 2 randomized controlled trials for patients with subacute and chronic low back pain at a CAM research center. Journal of Alternative and Complementary Medicine. 2008;14(8):983-992.
Hong E S, Deng M Y, Cheng L H, et al. [Effect of vertebral manipulation therapy on vertebro-basilar artery blood flow in cervical spondylosis of vertebral artery type]. [Chinese]. Zhongguo Zhong Xi Yi Jie He Za Zhi Zhongguo Zhongxiyi Jiehe Zazhi/Chinese Journal of Integrated Traditional & Western Medicine/Zhongguo Zhong Xi Yi Jie He Xue Hui Zhongguo Zhong Yi Yan Jiu Yuan Zhu Ban. 2005;25(8):742-744.
Horrigan B J. New Auricular Therapy Providing Pain Relief to Some Patients. Explore: The Journal of Science and Healing. 2008;4(4):228-231.
Hough E, Stephenson R, Swift L. A comparison of manual therapy and active rehabilitation in the treatment of non specific low back pain with particular reference to a patient's Linton & Hallden psychological screening score: a pilot study. BMC Musculoskeletal Disorders. 2007;8:106. 2007.106, 2007. [pmid: 17976243].
Huang S R, Lin Q X, Tang J, et al. [Study on the needling depth of point Yaotu with CT scanning]. [Chinese]. Zhongguo Zhenjiu. 2006;26(9):635-638.
Hurley D. Massage is better than acupuncture (and in the short term better than self-care) in reducing pain and disability in patients with chronic low back pain. Australian Journal of Physiotherapy. 2001;47(4):299. [pmid: 11774827].
Hurley D A, Baxter G D. Randomised controlled trial of spinal manipulation and electrotherapy in the physiotherapy management of acute low back pain [Abstract]. Joint meeting of the Royal Academy of Medicine in Ireland and British Orthopaedic Reserach Society In: Journal of Bone and Joint Surgery British Volume. Suppl. 1999;81:3323.
Hurley D A, McDonough S M, Baxter G D, et al. A descriptive study of the usage of spinal manipulative therapy techniques within a randomized clinical trial in acute low back pain. Manual Therapy. 2005;10(1):61-67. [pmid: 15681270].
Imamura S T. Efficacy of myofascial therapy in failed back surgery. Acupuncture and Electro-Therapeutics Research. 2006;31(1-2):163-164.
Indahl A, Velund L, Reikeraas O. Good Prognosis for Low Back Pain When Left Untampered: A Randomized Clinical Trial. Spine. 1995;20(FEB):473-477. [pmid: 7747232].
Irnich D, Behrens N, Molzen H, et al. Acupuncture - Superplacebo for backache?. [German]. Forschende Komplementarmedizin und Klassische Naturheilkunde. 2001;8(6):387-388.
Irnich De. Acupuncture in chronic neck pain:an overview and results of a randomized large scale trial of acupuncture compared with conventional massage and sham laser acupuncture. Deutsche Zeitschrift fur Akupunktur. 2001;44(2a):205.
Ishimaru K, Shinohara S, Kitade T, et al. Clinical efficacy of electrical heat acupuncture (first report): effect on low back pain. American Journal of Acupuncture. 1993;21(1).
Jacobs K. Functional outcomes of low back pain: comparison of four treatment groups in a randomized controlled trial. [comment]. Journal of Manipulative & Physiological Therapeutics. 1992;15(9):609-610. [pmid: 1469348].
Jensen I B, Busch H, Bodin L, et al. Cost effectiveness of two rehabilitation programmes for neck and back pain patients: A seven year follow-up. Pain. 2009;142(3):202-208. [pmid: 19217717].
Jensen O K, Nielsen F F, Vosmar L. An open study comparing manual therapy with the use of cold packs in the treatment of post-traumatic headache. Cephalalgia. 1990;10(5):241-250. [pmid: 2272094].
Johnson I. Adverse effects of spinal manipulation (3). Journal of the Royal Society of Medicine. 2007;100(10):444-445. [pmid: 17911118].
Johnson R, Prasad K, Wong L, et al. Use of acupuncture following whiplash type injuries to the neck. Combined Services Orthopaedic Society: Millennium Meeting In: Journal of Bone and Joint Surgery British Volume. Suppl. 2000;82:3266.
Kalauokalani D, Cherkin D C, Sherman K J, et al. Lessons from a trial of acupuncture and massage for low back pain. Massage Therapy Journal. Spring. 2003;42(1):112-23. (34 ref) 2003; 42(1):112-123.
Kapral M K, Bondy S J. Cervical manipulation and risk of stroke. Canadian Medical Association Journal. 2001;165(7):907-908. [pmid: 11599330].
Kent P. Clinical rule predicts patients likely to benefit from spinal manipulation. Australian Journal of Physiotherapy. 2005;51(1):56. [pmid: 15803615].
Killinger L Z. [Commentary on] United Kingdom Back Pain Exercise and Manipulation (UK BEAM) randomised trial: cost effectiveness of physical treatments for back pain in primary care. D.C.Tracts. Fall. 2005;17(3):9-10. 13. 5. 2005;(3):9-10.
Killinger L Z. Local and remote sustained trigger point therapy for exacerbations of chronic low back pain: a randomized, double-blind, controlled, multicenter trial. D.C.Tracts. 2002;14(4):12-18.
Kim S Y, Park H J, Yin C S. Comment on the 'Randomised trial of trigger point acupuncture compared with other acupuncture for treatment of chronic neck pain'. Complementary Therapies in Medicine. Dec. 2008;16(6):363-4. 2008;16(6):363-364. [pmid: 19028337].
Kim S-Y, Park H-J, Yin C S. Comment on the “Randomised trial of trigger point acupuncture compared with other acupuncture for treatment of chronic neck pain". Complementary Therapies in Medicine. 2008;16(6):363-364. [pmid: 19028337].
Kongsted A, Qerama E, Kasch H, et al. Neck collar, “act-as-usual” or active mobilization for whiplash injury? A randomized parallel-group trial. Spine. 2007;32(6):618-626. [pmid: 17413465].
Kovacs F. Acupuncture does not produce a significant clinical effect in chronic neck pain. Australian Journal of Physiotherapy. 2005;51(1):54. [pmid: 15803613].
Kovacs F M, Abraira V, Pozo F, et al. Local and remote sustained trigger point therapy for exacerbations of chronic low back pain. A randomized, double-blind, controlled, multicenter trial. [see comment]. Spine. 1997;22(7):786-797. [pmid: 9106321].
Kraft K. Acupuncture massage vs. Swedish massage in chronic low back pain. Focus on Alternative and Complementary Therapies. 2001;6(2):111-112.
Krippendorf D J. Hurwitz EL Re:, Morgenstern H, Vassilaki M, Chiang LM, editors. Frequency and clinical predictors of adverse reactions to chiropractic care in the UCLA neck pain study. Spine. 2005;30:1477-84. [comment]. Spine 2006;31(2):251-252. [pmid: 15990659].
Kruse R A, Gudavalli S, Cambron J. Chiropractic treatment of pregnant patient with lumbar radiculopathy. J Chiropractic Med. 2007;6(4):153-158.
Kumar S. 'Usual' physiotherapy is more effective than brief physiotherapy for neck pain. Australian Journal of Physiotherapy. 2005;51(1):55. [pmid: 15803614].
Kwan O, Friel J, Hoving J L, et al. Effects of Three Therapies for Neck Pain [1] (multiple letters). Annals of Internal Medicine. 2003;138(8):685-686. [pmid: 12693897].
Kwasucki J, Zaleska B, Gierczak J. [Modified acupuncture in the treatment of pain]. [Polish]. Neurologia i Neurochirurgia Polska. 1978;12(3):229-234. [pmid: 683427].
Laird R. Manipulative therapy and back care education: a comparative trial of two treatment methods [abstract]. Australian Journal of Physiotherapy. 1988;34(1):56.
Lawrence D J. A single high-velocity low-amplitude manipulation of the cervical spine improves pain and mobility compared to control mobilisation: Commentary. Focus on Alternative and Complementary Therapies. 2007;12(1):43-44.
Lawrence D J. Cervical spine chiropractic manipulation and mobilisation confer comparable clinical results in a population of subjects with neck pain. Focus on Alternative and Complementary Therapies. 2003;8(1):55-56.
Lawrence D J. Clinical prediction rule for spinal manipulation does not discriminate patients in an Australian physiotherapy primary care setting. Commentary. Focus.on Alternative and Complementary Therapies. 2008;13(4):284-285.
Lawrence D J, Ernst E. Spinal manipulation for neck pain - More good than harm?. Focus on Alternative and Complementary Therapies. 2004;9(2):107-110.
Lawrence D J, Palmgren P J, Bjorndahl L. Chiropractic care may influence proprioceptive sensation and pain of cervical origin. Focus on Alternative and Complementary Therapies. Sep. 2006;11(3):222-4. (13 ref) 2006;(3):222-224.
Lebovits A, Hainline B, Stone L S, et al. Struck From Behind: Maintaining Quality of Life With Chronic Low Back Pain. Journal of Pain. 2009;10(9):927-931. Date of Publication: September 2009. 2009;(9):927-931. [pmid: 19712900].
Legge D. A Critical Appraisal of an Article Comparing the Effectiveness of Osteopathic Manipulation and Chemonucleolysis in the Management of Symptomatic Lumbar Disc Herniation. Journal of Osteopathic Medicine. OCT. 2002;5(2):81-82.
Legorreta A P, Metz R D, Nelson C F, et al. Comparative analysis of individuals with and without chiropractic coverage: patient characteristics, utilization, and costs. [see comment]. Archives of Internal Medicine. 2004;164(18):1985-1992. [pmid: 15477432].
Lehmann O J, Mendoza N D, Bradford R. Manipulative therapy and physiotherapy for persistent back and neck complaints. [comment]. BMJ. 1992;304(6837):1309-1. [pmid: 1535012].
Leibing E, Pfingsten M, Leichsenring F, et al. Molsberger AF Comment on:, Mau J, Pawelec DB, Winkler J., editors. Does acupuncture improve the orthopedic management of chronic low back pain?. Pain. 2002;99:579-87. [1] (multiple letters). Pain 2003;104(1-2):425-427. [pmid: 12406534].
Lemstra M, Olszynski W P. The effectiveness of standard care, early intervention, and occupational management in worker's compensation claims. Spine. 2003;28(3):299-304. [pmid: 12567037].
Lerner F, Kirsch D. A double-blind comparative study of micro-stimulation and placebo effect in short term treatment of the chronic back pain patient. ACA Journal of Chiropractic. NOV. 1981;18(11):S101-S106.
Lewit K. [The problem of manual and reflex-(neural)therapy]. [German]. Wiener Medizinische Wochenschrift. 1971;121(23):473-477. [pmid: 5110493].
Li J, Chenard J R, Marchand S, et al. Acupuncture points and trigger-points: Reactivity to pressure and skin response in patients with chronic low back pain. [French]. Rhumatologie. 1994;46(1):11-19.
Licciardone J C, Russo D P. Blinding protocols, treatment credibility, and expectancy: Methodologic issues in clinical trials of osteopathic manipulative treatment. Journal of the American Osteopathic Association. 2006;106(8):457-463. [pmid: 16943515].
Licht P B, Christensen H W, Hojgaard P, et al. Vertebral artery flow and spinal manipulation: a randomized, controlled and observer-blinded study. [erratum appears in J Manipulative Physiol Ther 1998 May;21(4):inside back cov]. Journal of Manipulative & Physiological Therapeutics. 1998;21(3):141-144. [pmid: 9567231].
Lind B K, Lafferty W E, Tyree P T, et al. The role of alternative medical providers for the outpatient treatment of insured patients with back pain. Spine. 2005;30(12):1454-1459. [pmid: 15959379].
Linde K. [Should acupuncture be reimbursed? Three acupuncture programmes of German Statutory Health Insurance Funds (SHI) and their scientific evaluation]. [German]. Zeitschrift fur Arztliche Fortbildung und Qualitatssicherung. 2004;98(6):467-468. [pmid: 15527186].
Lipton JA M E N E. Improved Pain Score Outcomes Achieved Through The Cooperative and Cost-Effective Use of Physical (Osteopathic Manipulative) Medicine in the Treatment of Outpatient Musculoskeletal Complaints. The American Academy of Osteopathy Journal. SPR. 2002;12(1):26-32.
Liu G U I, Zhen L I L. [Clinical analysis of the treatment of intervertebral disc protrusion by warming acupuncture and massage combined with herbal fomentation]. Shanghai journal of acupuncture and moxibustion. 2002;21(4):26.
Liu X M, Li Q H, Ding M H, et al. [Therapy effect of intrathecal, nerve stem and pain pressure point electroacupuncture in severe refractory back and leg pains]. [German]. Acta Academiae.Medicinae.Wuhan. 1984;4(4):248-251. [pmid: 6241302].
Liu Y, Cai G N. [Clinical experience in treating lumbar intervertebral disc prolapse by acupuncture and moxibustion plus traction]. Shanghai journal of acupuncture and moxibustion. 2004;23(04):18-19.
Long C R. Effectiveness of spinal manipulative therapy in the treatment of mechanical thoracic spine pain: a pilot randomized clinical trial. [comment]. Journal of Manipulative & Physiological Therapeutics. 2002;25(8):538. 2002. [pmid: 12381977].
Loy T T. Treatment of cervical spondylosis. Electroacupuncture versus physiotherapy. Medical Journal of Australia. 1983;2(1):32-34. [pmid: 6346029].
Lund I, Naslund J, Lundeberg T. Minimal acupuncture is not a valid placebo control in randomised controlled trials of acupuncture: A physiologist's perspective. [German]. Deutsche Zeitschrift fur Akupunktur. 2009;52(2):55-56. Date of Publication: 2009. 2009;(2):55-56.
Maher C. AJP Forum: Pre-manipulative testing of the cervical spine. Australian Journal of Physiotherapy. 2001;47(3):163-164. [pmid: 11675704].
Maiers M J, Hartvigsen J, Schulz C, et al. Chiropractic and exercise for seniors with low back pain or neck pain: the design of two randomized clinical trials. BMC Musculoskeletal Disorders. 2007;8:94. 2007.94, 2007. [pmid: 17877825].
Maiers M, Evans R, Bronfort G. The Interpretation of Patient-Oriented Outcome Measures in Low Back Pain Patients: Combining Qualitative and Quantitative Research Methods. The Journal of Chiropractic Education. SPR. 2002;16(1):82.
Malmqvist S, Leboeuf-Yde C, Ahola T, et al. The Nordic back pain subpopulation program: Predicting outcome among chiropractic patients in Finland. Chiropractic and Osteopathy. 2008;16. 2008. Article Number: 13. Date of Publication: 07 Nov 2008.
Mameli S, Pili A, Melis R, et al. Trattamento del dolore miofasciale con tens ed elettroagopuntura. Gionale Ital Riflessoter Agopunt. 1995;7(2):11-16.
Manchikanti L, Singh V, Fellows B, et al. Evaluation of influence of gender, occupational injury, and smoking on chronic low back pain of facet joint origin: A subgroup analysis. Pain Physician. 2002;5(1):30-35. [pmid: 16896355].
Marshall P, Murphy B. Self-report measures best explain changes in disability compared with physical measures after exercise rehabilitation for chronic low back pain. Spine. 2008;33(3):326-338. [pmid: 18303467].
Martin B I, Deyo R A, Mirza S K, et al. Expenditures and health status among adults with back and neck problems. JAMA. 2008;299(6):656-664. [pmid: 18270354].
Matsumoto T, Levy B, Ambruso V. Clinical evaluation of acupuncture. American Surgeon. 1974;40(7):400-405. [pmid: 4600648].
Mccarthy M. Palpatory literacy, Chinese therapeutic bodywork (Tui Na) and the remediation of head, neck and shoulder pain. Journal of Bodywork and Movement Therapies. OCT. 2003;7(4):262-277.
McDonough S M, Kennedy S, Bradbury I, et al. Acupuncture for acute non-specific low back pain: a pilot randomised sham controlled trial. 13th Annual Symposium on Complementary Health Care. 12th-14th December, 2006. University of Exeter, UK. Focus on Alternative and Complementary Therapies. Supplement 1. 2006;11:30. 2006;30.
McDonough S M, Liddle S D, Hunter R, et al. Exercise and manual auricular acupuncture: a pilot assessor-blind randomised controlled trial. (The acupuncture and personalised exercise programme (APEP) trial). BMC Musculoskeletal Disorders. 2008;9:31. 2008.31, 2008. [pmid: 18325114].
McKinney L A, Dornan J O, Ryan M. The role of physiotherapy in the management of acute neck sprains following road-traffic accidents. Arch Emerg Med. 1989;6(1):27-33. [pmid: 2712985].
McMakin C. Microcurrent treatment of myofascial pain in the head, neck, and face. Topics in Clinical Chiropractic. Mar. 1998;5(1):29-35. 73. 5. (9 ref) 1973;(1):29-35.
Meade T. Comparison of Chiropractic and Hospital Out-Patient Management of Low Back Pain: A Feasibility Study. Journal of Epidemiology and Community Health. 1986;40(MAR):12-17. [pmid: 2872260].
Meade T, Dyer S, Browne W, et al. Randomised comparison of chiropractic and hospital outpatient management for low back pain: results from extended follow-up. D.C.Tracts. Fall. 11. 1999;11(3):8-2. 1911;(3):8.
Meal G. A clinical trial investigating the possible effect of the supine cervical rotary manipulation and the supine rotary break manipulation in the treatment of mechanical neck pain: a pilot study. [comment]. Journal of Manipulative & Physiological Therapeutics. 2002;25(8):541-542. [pmid: 12381981].
Medeiros J M. Massage for Low-Back Pain - Will It Benefit My Patient?. Journal of Manual and Manipulative Therapy. 2003;11(3):134-135.
Medeiros J M. Cervical spine manipulation - Is it safe?. Journal of Manual and Manipulative Therapy. 2001;9(4):187-189.
Meek J, Lopacz S. Colchicine confirmed as highly effective in disk disorders: final results of a double-blind study. J Neurol Orthop Med Surg. 1985:6211-218.
Molde Hagen E, Grasdal A, Eriksen H R. Does early intervention with a light mobilization program reduce long-term sick leave for low back pain: a 3-year follow-up study. Spine. 2003;28(20):2309-2315. [pmid: 14560075].
Molsberger Af E T. Does acupuncture contribute to the treatment of chronic low back pain (CLBP). Deutsche Zeitschrift fur Akupunktur. 2001;44(2a):234.
Molsberger A, et al. Is acupuncture effective in the treatment of chronic pain start of the so far largest randomized controlled acupuncture trials with patients blind to acupuncture method. J Altern Complement Med. 2004;10(1):216-216.
Molsberger A F. Does acupuncture improve conventional orthopedic pain treatment in the management of chronic low back pain (CLBP). Deutsche Zeitschrift fur Akupunktur. 2001;44(2a):207.
Moon M H, Han D W, Lee H S, et al. The effectiveness of acupuncture in patients with low back pain in Korea. 13th Annual Symposium on Complementary Health Care. 12th-14th December, 2006. University of Exeter, UK. Focus on Alternative and Complementary Therapies. Supplement 1. 2006;11:31. 2006;31.
Mooney V. Manual therapy and exercise therapy in patients with chronic low back pain: a randomized, controlled trial with 1-year follow-up. [comment]. Spine. 2004;29(1):107-108. [pmid: 14699287].
Mooney V. Manual therapy with steroid injections--a new approach to treatment of low back pain. [comment]. Spine. 1994;19(20):2372-2373. [pmid: 7846587].
Mooney V, Aure O F, Vasseljen O. Aure OF To the editor... Re:, Nilsen JH, Vasseljen O, editors. Manual therapy and exercise therapy in patients with chronic low back pain: a randomized, controlled trial with 1-year follow-up. Spine. 2003;28:525-531. Spine 2004;29(1):107-108. [pmid: 12642755].
Moritz S, Quan H, Liu M F. Acupuncture for lower back pain and health resource use. 12th Annual Symposium on Complementary Health Care -- Abstracts. 19th-21st September 2005. Exeter, UK. Focus on Alternative and Complementary Therapies. Supplement 1. 2005;10:39. 2005;39.
Moroz A, Spivack S, Lee M H M. Adherence to acupuncture treatment for chronic pain [2]. Journal of Alternative and Complementary Medicine. 2004;10(5):739-740.
Multiple A U T H. Abstracts of ACC Conference Proceedings: Platform presentations [ACC contributed papers presented at the 2000 Association of Chiropractic Colleges Seventh Annual Conference]. J Chiropr Educ. 2000;14(1):1-26.
Multiple A U T H. Abstracts of ACC Conference Proceedings: Platform presentations [ACC contributed papers presented at the 2007 Association of Chiropractic Colleges Educational Conference XIV and Research Agenda Conference XII]. J Chiropr Educ. 2007;21(1):47-93.
Multiple A U T H. Abstracts of ACC Conference Proceedings: Platform presentations [ACC contributed papers presented at the 2008 Association of Chiropractic Colleges Educational Conference XV and Research Agenda Conference XIII]. J Chiropr Educ. 2008;22(1):48-82.
Myler L. A risk assessment of cervical manipulation vs. NSAIDs for the treatment of neck pain. Journal of Manipulative & Physiological Therapeutics. 1996;19(5):357. 1996. [pmid: 8792325].
Najm W I. German acupuncture trials (GERAC) for chronic low back pain. Medical Acupuncture. 2008;20(2):131-132.
Newton D. The place of manipulation treatment in lesion of the lumbar spine. Postgraduate Medical Journal. 1958;(34):378-381. [pmid: 13567162].
Nicholson W R. Chronic spinal pain syndromes: a clinical pilot trial comparing acupuncture, a nonsteroidal anti-inflammatory drug, and spinal manipulation. [comment]. Journal of Manipulative & Physiological Therapeutics. 2000;23(4):297-298. [pmid: 10820308].
Nilsson N, Christensen H W, Hartvigsen J. Lasting changes in passive range motion after spinal manipulation: a randomized, blind, controlled trial. Journal of Manipulative and Physiological Therapeutics. 1996;19(3):165-168. [pmid: 8728459].
Nordemar R, Thorner C. Treatment of acute cervical pain--a comparative group study. Pain. 1981;10(1):93-101. [pmid: 6972028].
Nuwayhid I A, Stewart W, Johnson J V. Work activities and the onset of first-time low back pain among New York City fire fighters. American Journal of Epidemiology. 1993;137(5):539-548. [pmid: 8465805].
Nwuga V C. Relative therapeutic efficacy of vertebral manipulation and conventional treatment in back pain management. American Journal of Physical Medicine. 1982;61(6):273-278. [pmid: 6216814].
Ott S M. Physical therapy, chiropractic manipulation, or an educational booklet for back pain. [comment]. New England Journal of Medicine. 1999;340(5):389-390. [pmid: 9988609].
Ozcan E, Ozturk Y, Dincer N, et al. Efficacy of acupuncture in the treatment of chronic neck pain. [Turkish]. Turkiye.Fiziksel.Tip.ve.Rehabilitasyon Dergisi. 2003;49(6):23-27.
Palmieri N F, Smoyak S. Chronic low back pain: a study of the effects of manipulation under anesthesia. Journal of Manipulative & Physiological Therapeutics. 2002;25(8):E8-E17. [pmid: 12381983].
Park J, Linde K, Manheimer E, et al. The status and future of acupuncture clinical research. Journal of Alternative & Complementary Medicine. 2008;14(7):871-881.
Parsons G. Acupuncture was better than no acupuncture but did not differ from minimal (sham) acupuncture for chronic low back pain at 8 weeks. [comment]. Evidence-Based Nursing. 2006;9(4):111. 2006. [pmid: 17039640].
Patterson M M, Carter K. Lumbar rotation range of motion with lumbar osteopathic manipulative treatment. The Journal of the American Osteopathic Association. AUG. 2003;103(8):382.
Pedigo M D. Physical therapy, chiropractic manipulation, or an educational booklet for back pain. [comment]. New England Journal of Medicine. 1999;340(5):388-1. [pmid: 9988604].
Pelletier K R. Integrative medicine: Sorting fact from fiction. MedGenMed Medscape General Medicine. 2007;9(4). 2007. Article Number: 26. Date of Publication: 2007.):.
Peloso P M, Gross A. Further studies are needed to assess the competing therapies for neck pain. [see comment]. Journal of Pain. 2003;4(8):422-426. [pmid: 14622660].
Perry J. The effects of unilaterally applied lumbar mobilization technique on peripheral sympathetic activity in the lower limbs. Manual Therapy. AUG. 2003;8(3):186.
Persi A. Safety in chiropractic practice. Part II: Treatment to the upper neck and the rate of cerebrovascular incidents. Journal of Manipulative & Physiological Therapeutics. 1997;20(8):566-567. [pmid: 9345688].
Pittler M H. Static magnets for reducing pain. Focus on Alternative and Complementary Therapies. 2008;13(1):5-10.
Plaugher G, Abend D S, Morehouse M, et al. Osteopathy, chiropractic, and spinal manipulation [4]. Annals of Internal Medicine. 1993;118(8):651-653. [pmid: 8452339].
Pollard H. The effect of chiropractic manipulation on chronic neck pain in women aged between 30 and 40. Proceedings Of The World Federation Of Chiropractic Congress. 2001;6312.
Poole H, Murphy P, Glenn S. Evaluating the efficacy of reflexology for the management of chronic low back pain. Focus on Alternative and Complementary Therapies. MAR. 2002;7(1):105-106.
Rapp S M. Acupuncture mitigates chronic low back pain 20% better than conventional care. Orthopedics Today. Dec. 2007;27(12):49-50. (2 ref) 2007;(12):49-50.
Reginiussen T, Johnsen R, Torstensen T A. Efficiency of manual therapy on patients with cervicogenic headache: A Randomized single blinded controlled trial: Abstract 105. International Federation of Manipulation Therapy, 7th Scientific Conference. 2000.
Reilich P. Myofascial Pain Syndrome. [German]. MMW-Fortschritte der Medizin. 2007;149(43):44-46. [pmid: 17992905].
Resch K L. Subacute spinal pain: Osteopathy as a useful and cost effective add-on to usual care. Dtsch Z Osteopath. 2005;3(1):7-8.
Richardson W. Myofascial Trigger Points and Acupuncture. European Journal of Oriental Medicine. 2001;3(SUM):38-47.
Rivett D A. Adverse events and the vertebral artery: Can they be averted?. Manual Therapy. 2006;11(4):241-242. [pmid: 17035066].
Robertshawe P. Effects of traditional Thai massage versus Swedish massage for back pain. Journal of the Australian Traditional-Medicine Society. Jun. 2007;13(2):97. 127. 2007;(2):97.
Ronge R. A German study has proven - Effectiveness of acupuncture in the treatment of chronic low back pain. [German]. Gesundheitsokonomie.und Qualitatsmanagement. 2008;13(1):45.
Rosner A L. Comparing the costs between provider types of episodes of back pain care. [comment]. Spine. 1995;20(23):2595-2598. [pmid: 8610258].
Rosner A L Re:, editor. Chiropractic manipulation and stroke [3]. Stroke. 2001;32(9):2207-2208. [pmid: 11546921].
Rosner A L. Adverse reactions to chiropractic care in the UCLA neck pain study: a response. Journal of Manipulative and Physiological Therapeutics. Mar-Apr. 2006;29(3):248-51. (56 ref) 2006;29(3):248-251. [pmid: 16584952].
Rossman M L, Wexler J, Oyle I. The Use of Sonopuncture in Some Common Clinical Syndromes. American Journal of Chinese Medicine. 1974;(2):199-201.
Rotchford J K. Review of Acupuncture for chronic low back pain in older patients: a randomized, controlled trial (Meng,C.L; et al). Acubriefs Newsletter. 2003;4(8).
Rotchford J K. Abstract of Does acupuncture improve the orthopedic management of chronic low back pain - a randomized, blinded, controlled trial with 3 months follow up (Molsberger,A.F; et al). Acubriefs Newsletter. 2002;3(11).
Rotchford J K. Abstract of Randomized Trial Comparing Traditional Chinese Medical Acupuncture, Therapeutic Massage, and Self-care Education for Chronic Low Back Pain. (Cherkin,D.C; Eisenberg,D; Sherman,K.J; et al). Acubriefs Newsletter. 2001;2(5).
Rotchford J K. Abstract of Relief of chronic neck and shoulder pain by manual acupuncture to tender points-a sham-controlled randomized trial (Nabeta,T; et al). Acubriefs Newsletter. 2003;4(3).
Rotchford J K. Abstract of Immediate effects of dry needling and acupuncture at distant points in chronic neck pain: results of a randomized, double-blind, sham- controlled crossover trial (Irnich,D; et al). Acubriefs Newsletter. 2002;3(9).
Rotchford J K. Abstract of Randomised clinical trial comparing the effects of acupuncture and a newly designed placebo needle in rotator cuff tendinitis (Kleinhenz,J; Streitberger,K; Windeler,J; et al). Acubriefs Newsletter. 2001;2(5).
Rotchford J K. Abstract of Randomised trial of acupuncture compared with conventional massage and sham laser acupuncture for treatment of chronic neck pain (Irnich,D; Behrens,N; Molzen,H; et al). Acubriefs Newsletter. 2001;2(6).
Rotchford J K. View Citation. Abstract of Chronic Spinal Pain: A Randomized Clinical Trial Comparing Medication, Acupuncture, and Spinal Manipulation (Giles, L.G; et al). Acubriefs Newsletter. 2003;4(7).
Rupert R. The effectiveness of physical modalities among patients with low back pain randomized to chiropractic care: findings from the UCLA low back pain study. [comment]. Journal of Manipulative & Physiological Therapeutics. 2002;25(8):538-539. [pmid: 12381978].
Ryan J, Corry J, Speldewinde G. Endurance training to be no more effective than physiotherapy or chiropractic treatment in terms of reducing pain and disability or increasing muscle strength. [comment]. Spine. 1998;23(19):2147-2149. [pmid: 9794063].
Sator-Katzenschlager S M, Scharbet G, Kozek-Langenecker S A, et al. Chronic low back pain: Potential for treatment by electrostimulation of auricular acupuncture points. Focus on Alternative and Complementary Therapies. 2005;10(1):37-38.
Saunders C. Manual therapy for low back pain. Patient Care. 2001;35(10):19-23.
Schiltenwolf M, Althaus E. First-line treatment for acute low back pain: Assessment of diclofenac or spinal manipulative therapy. [German]. Schmerz. 2008;22(4):468-470. [pmid: 18481114].
Schnabel M, Vassiliou T, Schmidt T, et al. [Results of early mobilisation of acute whiplash injuries]. Schmerz. 2002;16(1):15-21. [pmid: 11845337].
Schockert T. The effectiveness of Yamamoto New Scalp Acupuncture (YNSA) for the relief of pain of the locomotor system - An open, prospective, topometrically controlled study. [German]. Deutsche Zeitschrift fur Akupunktur. 2002;45(2):93-100.
Schrader P. Manual osteopathic therapy in the treatment of lumboischialgic disorders. [German]. Padiatrische.Praxis. 2003;62(3):479-480.
Seaman D. The subluxation complex: the adjustment puts bones out of place?. Dynamic Chiropractic. Dec. 17. 2007;25(26):20. 25. (9 ref) 2007;(26):20.
Secher O. [Traction compared with chiropractic treatment]. [Danish]. Ugeskrift for Laeger. 1969;131(26):1122-1125. [pmid: 4240388].
Sharma R, Haas M, Stano M. Patient attitudes, insurance, and other determinants of self-referral to medical and chiropractic physicians. American Journal of Public Health. 2003;93(12):2111-2117. [pmid: 14652343].
Shaughnessy A. Is spinal manipulation more effective than other treatments for low back pain?. Evidence-Based Practice. Nov. 2003;6(11):2-3. 2p. 2002;(11):2-3.
Shekelle P. Acupuncture for low back pain. [comment]. Annals of Internal Medicine. 2005;143(9):691-692. [pmid: 16263896].
Shekelle P. Cervical spine manipulation was not better than mobilization for improving outcomes in neck pain. ACP Journal Club. 2003;138(2):48. [pmid: 12614133].
Shekelle P G. The use and costs of chiropractic care in a community-based sample of the United States (back pain). Dissertation Abstracts Series B. 1994;55(03):847.
Sherman K. Pragmatic mega-trial of acupuncture: Does acupuncture benefit persons with neck pain? Commentary. Forschende Komplementarmedizin. 2007;14(1):45-46.
Sherman K J. Acupuncture for neck pain: Are there any benefits?. Focus on Alternative and Complementary Therapies. 2005;10(3):205-206.
Sherman K J. Electro-acupuncture reduces pain and dysfunction in chronic lumbar pain patients. Focus on Alternative and Complementary Therapies. Mar. 2004;9(1):39-40. (2 ref) 2004;(1):39-40.
Sherman K J, Hawkes R J, Ichikawa L, et al. Comparing recruitment strategies in a study of acupuncture for chronic back pain. BMC Medical Research Methodology. 2009;9(1). Article Number: 69.Date of Publication: 2009. 2009;(1).
Sikorski J M. A rationalized approach to physiotherapy for low-back pain. Spine. 1985;10(6):571-579. [pmid: 2934830].
Silber J S, Giles L G F, Muller R. Giles LG Re:, Muller R, editors. Chronic spinal pain: A randomized clinical trial comparing medication, acupuncture, and spinal manipulation. Spine 2003;28:1490-502 [2] (multiple letters). Spine. 2004;29(5):596-597. [pmid: 15129082].
Simon T. A randomized clinical trial of manual therapy and physiotherapy for persistent back and neck complaints: subgroup analysis and relationship between outcome measures. [comment]. Journal of Manipulative & Physiological Therapeutics. 1994;17(2):128. 1994. [pmid: 8169542].
Simons D G. Myofascial Pain Syndromes - Trigger Points. Journal of Musculoskeletal Pain. WIN. 2002;10(4):71-85.
Simons D G, Dommerholt J. Myofascial pain syndromes - Trigger points. Journal of Musculoskeletal Pain. 2007;15(2):69-84.
Simons D G, Dommerholt J. Myofascial pain syndromes - Trigger points. Journal of Musculoskeletal Pain. 2005;13(4):39-48.
Simons D G, Dommerholt J. Effectiveness of traditional Thai massage versus Swedish massage among patients with back pain associated with myofascial trigger points. Journal of Musculoskeletal Pain. 2006;14(1):59.
Skillgate E, Vingard E, Alfredsson L. Naprapathic manual therapy or evidence-based care for back and neck pain: a randomized, controlled trial. Clinical Journal of Pain. 2007;23(5):431-439. [pmid: 17515742].
Slater R N S, Spencer J D. Central lumbar disc prolapse following chiropractic manipulation: A call for audit of 'alternative practice'. Journal of the Royal Society of Medicine. 1992;85(10):637-638. [pmid: 1433048].
Sneag D B, Bendo J A. Pregnancy-related low back pain. Orthopedics. Oct. 2007;30(10):839-47. (62 ref) 2007;30(10):839-847. [pmid: 17990410].
Snodgrass S J, Rivett D A, Robertson V J. Measuring the posteroanterior stiffness of the cervical spine. Manual Therapy. 2008;13(6):520-528. [pmid: 17910931].
Soeken K L. Effectiveness of acupuncture for pain remains unclear. Focus on Alternative and Complementary Therapies. 2000;5(4):265-266.
Soyuncu S. Back pain in adult: what's your diagnosis? Suction bullae and burning injury. European Journal of Emergency Medicine. 2009;16(1):57. 2009. [pmid: 19106721].
Spaar A. Acupuncture treatment for chronic low back pain. [German]. Schweizerische Rundschau fur Medizin - Praxis. 2009;98(16):911-912. Date of Publication: 2009. 2009;(16):911-912.
Sran M, Khan K, Ernst E. Spinal manipulation versus mobilization [4] (multiple letters). Canadian Medical Association Journal. 2002;167(1):13-14. [pmid: 12137068].
Stenchever M A. Manipulative therapy no better than other methods of back pain relief. ACOG Clinical Review. Sep. 2003;8(8):11. 2003;8(8):11.
Stern P J. Hattage. Journal of Bone and Joint Surgery - Series A. 2007;89 A(12):2803-2809.
Stig L C, Nilsson O, Leboeuf-Yde C. Recovery Pattern of Patients Treated With Chiropractic Spinal Manipulative Therapy for Long-lasting or Recurrent Low Back Pain. Journal of Manipulative and Physiological Therapeutics. MAY. 2001;24(4):288-291. [pmid: 11353940].
Szczurko O, Cooley K, Busse J W, et al. Naturopathic care for chronic low back pain: a randomized trial. PLoS ONE [Electronic Resource]. 2007;2(9):e919. 2007.
Szczurko O, Cooley K, Mills E, et al. Determining the impact of naturopathic treatment on Canadian postal workers with low back pain, a randomised controlled parallel group study. 13th Annual Symposium on Complementary Health Care. 12th-14th December, 2006. University of Exeter, UK. Focus on Alternative and Complementary Therapies. Supplement 1. 2006;11:46. 2006;46.
Tay A, Chua K, Chan K F. Upper Quarter Myofascial Pain Syndrome in Singapore: Characteristics and Treatment. Journal of Musculoskeletal Pain. 2000;8(4):49-56.
Teng C. Effect of acupuncture and physical therapy. Archive of Physical Medicine and Rehabilitation. 1973;53601.
ter Riet G. Long-term effects of traditional Finnish bone-setting for back pain. Focus on Alternative and Complementary Therapies. 2002;7(4):364-366.
ter Riet G. Evidence that manual therapy is superior to exercise therapy from a small, but carefully conducted trial. Focus on Alternative and Complementary Therapies. Dec. 2003;8(4):437-8. 2003;(4):437-438.
Thomas K J, MacPherson H, Ratcliffe J, et al. Longer term clinical and economic benefits of offering acupuncture care to patients with chronic low back pain (Provisional record). Health Technology Assessment. 2005;32(9):ii-iv.
Thomas K J, Fitter M, Brazier J, et al. Making research relevant - design of a pragmatic RCT of clinical and cost effectiveness of acupuncture in a primary care setting. Focus on Alternative and Complementary Therapies. MAR. 2001;6(1):93-94.
Thurlow R D. Odontoid agenesis with atlanto-axial luxation. Journal - Canadian Chiropractic Association. 1986;30(2):77-80.
Triano J J. [Letter] Conservative Treatment of Acute and Chronic Nonspecific Low Back Pain. Spine. 1998;23(JUN):1288-1291. [pmid: 9636984].
Tsukayama H, et al. Electro-acupuncture for back pain. Fact. 2003;8(2):258-258.
Underwood M. A clinical prediction rule predicted outcome in patients with low back pain having spinal manipulation and exercise treatment. Evidence-Based Medicine. Aug. 2005;10(4):125. (1 ref) 2005;(4):125.
Unknown. New Clinical Perspectives on Lumbar Disc Herniation. Spinal Manipulation. JAN. 1990;5(4):1-3.
Urrutia G, Burton A K, Morral A, et al. Neuroreflexotherapy for non-specific low-back pain. Cochrane Database of Systematic Reviews. 2004;(2):(CD003009). 2004.
van Tulder M. Promising results of manipulative therapy and exercise in the treatment of cervicogenic headache. Focus on Alternative and Complementary Therapies. 2003;8(2):216-218.
van Tulder M. Pilot study shows promising results for chiropractic spinal manipulation in chronic back and neck pain. Focus on Alternative and Complementary Therapies. 2000;5(1):30-31.
Vanderbilt S. Back to basics: massage therapy for low back pain. Massage and Bodywork. 2002;17(2):100-104.
Vann E G. Chiropractic versus medical management. [comment]. Journal of Occupational Medicine. 1991;33(12):1208. 1991. [pmid: 1819273].
Vas J, Perea-Milla E, Mendez C, et al. Efficacy and safety of acupuncture for the treatment of non-specific acute low back pain: a randomised controlled multicentre trial protocol [ISRCTN65814467]. BMC Complementary & Alternative Medicine. 2006;6:14. 2006.14, 2006. [pmid: 16630342].
Vernon H. A comparison of the effectiveness of spinal manipulative therapy for low back pain patients with and without spondylolisthesis. Journal of Manipulative & Physiological Therapeutics. 1987;10(6):337-338. [pmid: 2963886].
Vicenzino B, Collins D, Benson H, et al. An investigation of the interrelationship between manipulative therapy- induced hypoalgesia and sympathoexcitation. Journal of Manipulative and Physiological Therapeutics. 1998;21(7):448-453. [pmid: 9777544].
Vickers A. Acupuncture for treatment for chronic neck pain. Reanalysis of data suggests that effect is not a placebo effect. [comment]. BMJ. 2001;323(7324):1306-1307. [pmid: 11764758].
Vickers A. Acupuncture. Effective Health Care. Nov. 2001;7(2):1-11. (143 ref) 2001;(2):1-11.
View Citation. Study: Acupuncture Superior to Ultrasound for Shoulder Impingement. Acupuncture Today. 2006;7(3).
Wakefield A, Bull M, Greenough C G, et al. Comparing hospital and chiropractic treatment for back pain [8]. British Medical Journal. 1995;311(7015):1301-1302. [pmid: 7496253].
Wang Sheng-Xu E T. Electro-Acupuncture of Paravertebral Points Vs Conventional Points in Treatment of Lumbar Disc Protrusion. Int J Clin Acup. 2000;11(4):349-352.
Wang S M, Caldwell-Andrews A A, Fermo L, et al. Auricular acupuncture as a treatment for gestational low back pain: preliminary findings [abstract]. Anesthesiology. SupplA. 2002;96:1025. [pmid: 11964615].
Wang Z L, Chen L F, Zhu W M. [Observation on the transient analgesic effect of abdominal acupuncture TENS on pain of neck, shoulder, loin and legs]. [Chinese]. Zhongguo Zhenjiu. 2007;27(9):657-659.
Weber-Multhaupt C. Chirotherapie: Alternative bei funktionellen Schmerzsyndromen. Gesundes Leben. 1999;76(2):16-19.
Weidenhammer W, Wessel A, Melchart D. [Quality profile of a rehabilitation clinic for natural healing methods--Part 2: Patient and outcome profile]. [German]. Forschende Komplementarmedizin (2006.). 2007;14(6):335-345. [pmid: 18219208].
Weintraub M I. Spinal manipulative therapy is an independent risk factor for vertebral artery dissection. [comment]. Neurology. 2003;61(9):1314-1315. [pmid: 14666930].
Weintraub M I. Shiatsu massage therapy: A remarkable healing technique in spine pain. Journal of Back and Musculoskeletal Rehabilitation. 1996;7(3):195-197.
Wettig D. The acupuncture randomized trials study (back pain) was unblinded too early. [comment]. Archives of Internal Medicine. 2006;166(14):1527-1528. [pmid: 16864767].
White A. Acupuncture for chrome neck pain (n=135). Acupuncture in Medicine. 2005;23(2):87-88.
White A, Cummings M. Does acupuncture relieve pain?. BMJ. 2009;338(7690):303.
White A R. Acupuncture effective and efficacious for low back pain. Focus on Alternative and Complementary Therapies. 2003;8(2):211-212.
White A R. Acupuncture as an adjunct is better for back pain than physiotherapy alone. Focus on Alternative and Complementary Therapies. 2002;7(4):362-363.
White A R. Acupuncture improves back pain in pregnancy. Focus on Alternative and Complementary Therapies. 2001;6(1):8-9.
White A R. Comparing osteopathic manipulation and standard back pain care: more difficult than you think. Focus on Alternative and Complementary Therapies. 2000;5(2):131-132.
White A R. Japanese acupuncture for neck pain: Eastern promise?. Focus on Alternative and Complementary Therapies. 1999;4(2):63-64.
White D. Help desk. Is acupuncture effective for treatment of chronic low back pain?. Evidence-Based Practice. Aug. 2006;9(8):7. 12. 2p. (3 ref) 1912;(8):7.
White P, Lewith G T. Side-effects associated with acupuncture and a sham treatment: perhaps we should take a closer look at what is really responsible?[erratum appears in J Altern Complement Med. 2003 Jun;9(3):449]. Journal of Alternative & Complementary Medicine. 2003;9(1):16-19.
Wiles M R. “Dry needling of muscle motor points for chronic low-back pain: a randomized clinical trial with long-term follow-up” (Spine 1980;5:279-291). Spine. 1982;7(1):86. 1982-86, 1Feb. [pmid: 6461928].
Wilkey A. A national health service hospital (NHS) based study of the relative effectiveness of chiropractic manipulative treatment compared to normal outpatient pain clinic protocols in the management of chronic mechanical low back pain: a pilot study for a randomized clinical trial. Wfc's 7Th Biennial Congress Conference Proceedings. May 1 3, 2003. 2003:373.
Williams N. A Primary Care Musculoskeletal Clinic: Clinical and Financial Audit of twelve months activity;. Journal of Orthopaedic Medicine. 2000;22(2):48-51.
Williams N, Wilkinson C, Russell I, et al. Randomised osteopathic manipulation study (Romans): a pragmatic RCT based in primary care. Journal of Osteopathic Medicine. ARP. 2003;6(1):38-39.
Wilson S. Spinal manipulation and exercise for chronic neck pain: Are they more effective when delivered alone or in combination?. Australian Journal of Physiotherapy. 2001;47(4):300. [pmid: 11774828].
Witt C M, Brinkhaus B, Willich S N. [Acupuncture. Clinical studies on efficacy and effectiveness in patients with chronic pain]. [German]. Bundesgesundheitsblatt, Gesundheitsforschung, Gesundheitsschutz. 2006;49(8):736-742. [pmid: 16897149].
Wright G T. Assessing the risks of cervical manipulation for neck pain. [comment]. CMAJ Canadian Medical Association Journal. 2002;166(9):1134. 2002.
Xue C C. [Comparative study of spinal fractures in electric acupuncture convulsive therapy, electric convulsive therapy and epilepsy]. [Chinese]. Chung-Hua Shen. Ching. Ching. Shen. Ko Tsa Chih [Chinese Journal of Neurology & Psychiatry]. 1987;20(6):346-349.
Yamashita H. Trigger point acupuncture vs. 'standard' acupuncture - Is 'standard' acupuncture so ineffective?: Commentary. Focus on Alternative and Complementary Therapies. 2008;13(2):108-109.
Yamashita H. Conducting double-blind acupuncture trials with a press needle are possible, although this may no longer be the only way. Focus on Alternative and Complementary Therapies. 2009;14(4):310-311. Date of Publication: December 2009. 2009;(4):310-311.
Yang K, Nilsson N. Manipulation and cervicogenic headache... “A randomized controlled trial of the effect of spinal manipulation in the treatment of cervicogenic headache” (J Manipulative Physiol Ther 1995; 18:435-40). Journal of Manipulative and Physiological Therapeutics. May. 1996;19(4):282. 1996;(4):282. [pmid: 8734408].
Ye L H. [Clinical Study on Treatment of 53 Cases of Chronic Injury of Soft Tissues with Intra-cutaneous Catgut Embedding Therapy] (in Chinese). [Journal of Traditional Chinese Medicine]. 2004;45(11):829-830.
Yin Z-J, Chen X-M. Effect of clinostatic manipulation on blood flow velocity of patients with cervical spondylosis of vertebral artery type in supine position. [Chinese]. Chinese Journal of Clinical Rehabilitation. 2006;10(35):90-91.
Ylinen J, Kautiainen H, Wiren K, et al. Stretching exercises vs manual therapy in treatment of chronic neck pain: a randomized, controlled cross-over trial. Journal of Rehabilitation Medicine. 2007;39(2):126-132. [pmid: 17351694].
Young M. Safety of chiropractic interventions: a systematic review. Spine. 34(22):2476. (author reply 2476-2477), 2009.Date of Publication: 15 Oct 2009. 2009;(22):2476-2477. [pmid: 19829266].
Yu Y L, Chang C M, Lam T H. Cervical spondylotic radiculopathy precipitated by decompression sickness. British Journal of Industrial Medicine. 1990;47(11):785-787. [pmid: 2245190].
Yuan S-G, Zhao C-W, Xiao X, et al. Effect of Chinese and western medicine combined with acupuncture and massage on symptoms, hemorheology and cerebral-blood parameters in patients with vertebral artery type of cervical spondylosis. [Chinese]. Chinese Journal of Clinical Rehabilitation. 2006;10(15):26-28.
Zhan H. A study of cervical spondylosis treated with the chrysanthemum pillow with median hole and electroacupuncture. Journal of Chinese Medicine. 1996:5118-20.
Zhang W, Zhao X, Zhao X. 120 cases of sacroiliac joint subluxation treated with a combination of acupuncture and tuina. Inter J Clin Acup. 2005;14(3):173-176.
Zheng F-Z, Gao J, Cheng S-D, et al. Improvement of spinal motor function of patients with ankylosing spondylitis with magnetization herbs suppositories acupoints implant therapy: Follow-up of effect in half a year. [Chinese]. Chinese Journal of Clinical Rehabilitation. 2004;8(29):6436-6437.
Zhi L, Jing S. Clinical comparison between scalp acupuncture combined with a single body acupoint and body acupuncture alone for the treatment of sciatica. American Journal of Acupuncture. 1995;23(4):305-307.
Zito G, Jull G, Story I. Clinical tests of musculoskeletal dysfunction in the diagnosis of cervicogenic headache. Manual Therapy. 2006;11(2):118-129. [pmid: 16027027].
Zuil Escobar J C. [Chronic lower back pain; recommended exercises and joint movement]. [Spanish]. Enfermeria Clinica. 2009;19(5):289-290. [pmid: 19616465].
Zundorf A. Effectiveness of verum and sham acupuncture is similar in the treatment of low back pain. [German]. Deutsche Medizinische Wochenschrift. 2007;132(44):2304.

## Not a Relevant Intervention (Not a CAM or Multimodal Intervention)

Manual therapy for neck pain found more cost-effective. Rehab. Management. 2003;16(6):10. 2003.
Routine physiotherapy is as effective as one advice and assessment session for reducing disability in people with low back pain. Evidence-Based Healthcare and Public Health. 2005;9(2):129-130.
Training MDs to Adjust Offers “Little Extra Benefit,” Study Says. Dynamic Chiropractic. 2000;18(26). DEC.
The effectiveness of manual physical therapy and exercise for mechanical neck pain - a randomized clinical trial. Spine. 2008;33(22):2371-2378. [pmid: 18923311].
Orthopaedic manual therapy, McKenzie method or advice only for low back pain in working adults: a randomized controlled trial with one year follow-up. Journal of Rehabilitation Medicine. 2008;40(10):858-863. [pmid: 19242624].
Aigner N, Fialka C, Radda C, et al. Adjuvant laser acupuncture in the treatment of whiplash injuries: a prospective, randomized placebo-controlled trial. Wiener Klinische Wochenschrift. 2006;118(3-4):95-99. [pmid: 16703253].
Airaksinen O, Ntinen P. Effects of the electrical stimulation of myofascial trigger points with tension headache. Acupuncture & Electro-Therapeutics Research. 1992;17(OCT):285-290. [PMID 1362038].
Allan M, Brantingham J W, Mienezes A. Stretching as an adjunct to chiropractic manipulations of chronic neck pain - before, after or not at all? A prospective randomized controlled clinical trial. European Journal of Chiropractic. 2003;50(2):41-52.
Alvizatos J, Lamaro J, Fryer G. The effect of osteopathic treatment on people with sub-chronic and chronic neck pain: A pilot study. International Journal of Osteopathic Medicine. 2006;9(JUN):27.
Anderson B D. Randomized clinical trial comparing active versus passive approaches to the treatment of recurrent and chronic low back pain. 2005.
Andersson G B, Lucente T, Davis A M, et al. A comparison of osteopathic spinal manipulation with standard care for patients with low back pain. [see comment]. New England Journal of Medicine. 1999;341(19):1426-1431. [pmid: 10547405].
Atkinson M J. Relative effectiveness of combined spinal manipulative therapy and 'action potential' therapy versus combined spinal manipulative therapy and placebo 'action potential' therapy in the treatment of mechanical low back pain. European Journal of Chiropractic. 2002;49(2):157.
Aure O F, Nilsen J H, Vasseljen O. Multidisciplinary Pain. Abstracts: 47; . Physical Therapy (47). Pain Practice. MAR. 2004;4(1):65.
Bablis P, Pollard H, Bonello R. Neuro Emotional Technique for the treatment of trigger point sensitivity in chronic neck pain sufferers: A controlled clinical trial. Chiropractic & Osteopathy [Electronic Resource]. 2008;16:4. 2008.4, 2008.
Becker-Witt C, Jena S, et al. Effectiveness of acupuncture in 2807 patients with chronic low back pain in routine care. Fact. 2003;8(4):479-479.
Beira B, Peers A. A study of the effects of chiropractic therapy on the diameter of the spinal canal in patients with low back pain and radiculopathy. JNMS: Journal of the Neuromusculoskeletal System. Fall. 1998;6(3):114-26. (30 ref) 1998;(3):114-126.
Beurskens AJ, de Vet H C, van der, et al. The Efficiency of Traction for Lumbar Back Pain: Design of a Randomized Clinical Trial. J Manipulative Physiol Ther. 1995;18(3):141-147. [pmid: 7790793].
Bhatti TI, Gillin JC, Atkinson JH, et al. T'ai Chi Chih as a Treatment for Chronic Low Back Pain: A Randomized, Controlled Study. Alternative Therapies in Health and Medicine. MAR. 1998;4(2):90.
Bitterli J. [Manual therapy in spondylogenic headache (author's transl)]. [German]. Therapeutische Umschau. 1976;33(10):679-684. [pmid: 1006562].
Bitterli J, Graf R, Robert F, et al. [Objective criteria for the evaluation of chiropractic treatment of spondylotic headache (author's transl)]. [German]. Nervenarzt. 1977;48(5):259-262.
Blomberg S, Tibblin G. A controlled, multicentre trial of manual therapy with steroid injections in low-back pain: Functional variables, side effects and complications during four months follow-up. Clinical Rehabilitation. 1993;7(1):49-62.
Blomberg S, Hallin G, Grann K, et al. Manual therapy with steroid injections--a new approach to treatment of low back pain. A controlled multicenter trial with an evaluation by orthopedic surgeons. [see comment]. Spine. 1994;19(5):569-577. [pmid: 8184352].
Blomberg S, Svardsudd K, Mildenberger F. A controlled, multicentre trial of manual therapy in low-back pain. Initial status, sick-leave and pain score during follow-up. Scandinavian Journal of Primary Health Care. 1992;10(3):170-178. [pmid: 1410946].
Blomberg S, Svardsudd K, Mildenberger F. A Controlled, Multicentre Trial of Manual Therapy in Low Back Pain: Initial Status, Sick Leave and Pain Score During Follow-Up. Journal of Orthopaedic Medicine. 1994;16(1):2-8.
Blomberg S, Svardsudd K, Tibblin G. A randomized study of manual therapy with steroid injections in low-back pain. Telephone interview follow-up of pain, disability, recovery and drug consumption. European Spine Journal. 1994;3(5):246-254. [pmid: 7866845].
Bogefeldt J, Grunnesjo M I, Svardsudd K, et al. Sick leave reductions from a comprehensive manual therapy programme for low back pain: the Gotland Low Back Pain Study. Clinical Rehabilitation. 2008;22(6):529-541. [pmid: 18511533].
Boline P D, Kassak K, Bronfort G, et al. Spinal manipulation vs. amitriptyline for the treatment of chronic tension-type headaches: A randomized clinical trial. Journal of Manipulative and Physiological Therapeutics. 1995;18(3):148-154. [pmid: 7790794].
Botwin K, Sharma K, Saliba R, et al. Ultrasound-guided trigger point injections in the cervicothoracic musculature: a new and unreported technique. Pain Physician. 2008;11(6):885-889. [pmid: 19057634].
Bove G, Nilsson N. Spinal manipulation in the treatment of episodic tension-type headache: A randomized controlled trial. Journal of the American Medical Association. 1998;280(18):1576-1579. [pmid: 9820258].
Brealey S, Burton K, Coulton S, et al. UK Back pain Exercise And Manipulation (UK BEAM) trial--national randomised trial of physical treatments for back pain in primary care: objectives, design and interventions [ISRCTN32683578]. BMC Health Services Research. 2003;3(1):16. 2003. [pmid: 12892566].
Brennan G P, Fritz J M, Hunter S J, et al. Identifying subgroups of patients with acute/subacute “nonspecific” low back pain: Results of a randomized clinical trial. Spine. 2006;31(6):623-631. [pmid: 16540864].
Briem K, Huijbregts P, Thorsteinsdottir M. Immediate effects of inhibitive distraction on active range of cervical flexion in patients with neck pain: A pilot study. Journal of Manual and Manipulative Therapy. 2007;15(2):82-92. [pmid: 19066648].
Brinkhaus B, Witt C M, Jena S, et al. Interventions and physician characteristics in a randomized multicenter trial of acupuncture in patients with low-back pain. Journal of Alternative & Complementary Medicine. 2006;12(7):649-657.
British AoPM. Pain in the neck and arm: a multicentre trial of the effects of physiotherapy. British Medical Journal. 1966:1253-258. [pmid: 5178316].
Brockow T, Heissner T, Franke A, et al. Evaluation of the efficacy of subcutaneous carbon dioxide insufflations for treating acute non specific neck pain in general practice: A sham controlled randomized trial. European Journal of Pain: Ejp. 2008;12(1):9-16.
Brodin H. Inhibition - facilitation technique for lumbar pain treatment. Manual Medicine. 1987:324-26.
Brodin H. Cervical pain and mobilization. Manual Medicine. 1985:218-22.
Bronfort G. Chiropractic, asthma and the placebo effect. The final results of a randomized clinical trial. International Chiropractic Academy on the Study of Back Pain, Toronto, Canada; October 27-28, 1990. Journal of Manipulative & Physiological Therapeutics. 1991;(14):338.
Bronfort G, Evans R L, Anderson A V, et al. Nonoperative treatments for sciatica: a pilot study for a randomized clinical trial. Journal of Manipulative & Physiological Therapeutics. 2000;23(8):536-544. [pmid: 11050610].
Bronfort G, Evans R, Nelson B, et al. A randomized clinical trial of exercise and spinal manipulation for patients with chronic neck pain. Spine. 2001;26(7):788-797. [pmid: 11295901].
Bronfort G, Goldsmith C H, Nelson C F, et al. Trunk exercise combined with spinal manipulative or NSAID therapy for chronic low back pain: a randomized, observer-blinded clinical trial. Journal of Manipulative and Physiological Therapeutics. 1996;19(9):570-582. [pmid: 8976475].
Buerger A. A controlled trial of rotational manipulation in low back pain. Manuelle Medizin. 1980;(2):17-26.
Cairns M C, Foster N E, Wright C. Randomized controlled trial of specific spinal stabilization exercises and conventional physiotherapy for recurrent low back pain. Spine. 2006;31(19):E670-E681. [pmid: 16946640].
Cambron J A. Chiropractic care vs medical care for low back pain: Assessment of long-term follow-up data. 2005.
Cambron J A, Gudavalli M R, McGregor M, et al. Amount of health care and self-care following a randomized clinical trial comparing flexion-distraction with exercise program for chronic low back pain. Chiropractic & Osteopathy [Electronic Resource]. 2006;14:19. 2006.19, 2006.
Carey T S, Garrett J, Jackman A, et al. The outcomes and costs of care for acute low back pain among patients seen by primary care practitioners, chiropractors, and orthopedic surgeons. The North Carolina Back Pain Project. [see comment]. New England Journal of Medicine. 1995;333(14):913-917. [pmid: 7666878].
Carlsson J, Fahlcrantz A, Augustinsson L E. Muscle tenderness in tension headache treated with acupuncture or physiotherapy. Cephalalgia : an international journal of headache. 1990;10(3):131-141. [pmid: 2245458].
Cassidy J D. A blinded randomized clinical trial of manual therapy and physiotherapy for chronic back and neck complaints: physical outcome measures. [comment]. Journal of Manipulative & Physiological Therapeutics. 1992;15(5):332-333. [pmid: 1535361].
Chan D K, Johnson M I, Sun K O, et al. Electrical acustimulation of the wrist for chronic neck pain: a randomized, sham-controlled trial using a wrist-ankle acustimulation device. Clinical Journal of Pain. 2009;25(4):320-326. [pmid: 19590481].
Chan D, Goldberg R M, Mason J, et al. Backboard versus mattress splint immobilization: a comparison of symptoms generated. Journal of Emergency Medicine. 1996;14(3):293-298. [pmid: 8782022].
Chen X Y, Jia W H, Liu M J, et al. Observation on therapeutic effect of digital acupoint pressure for treatment of the nerve root type of cervical spondylosis. [Chinese]. Zhongguo zhen jiu = Chinese acupuncture & moxibustion. 2009;29(8):659-662. Date of Publication: Aug 2009. 2009;(8):659-662.
Chen XIAO, et al. [Dynamic b-ultrasonographic observation of the treatment of 80 patients with lumbar intervertebral disc prolapse by acupuncture-moxibustion plus three-palm massage]. Shanghai journal of acupuncture and moxibustion. 2001;20(6):14.
Chibnall J T, Tait R C. Long-term adjustment to work-related low back pain: Associations with sociodemographics, claim processes, and post-settlement adjustment. Pain Medicine. 2009;10(8):1378-1388. Date of Publication: November/December 2009. 2009;(8):1378-1388. [pmid: 20021598].
Chown M, Whittamore L, Rush M, et al. A prospective study of patients with chronic back pain randomised to group exercise, physiotherapy or osteopathy. Physiotherapy. 2008;94(1):21-28.
Clauw D J, Harris R E. Is acupuncture more effective than sham acupuncture in relieving pain in patients with low back pain?. Nature Clinical Practice Rheumatology. 2006;2(7):362-363.
Coppieters M W, Stappaerts K H, Wouters L L, et al. The immediate effects of a cervical lateral glide treatment technique in patients with neurogenic cervicobrachial pain. Journal of Orthopaedic and Sports Physical Therapy. 2003;33(7):369-378. [pmid: 12918862].
Couppe C, Torelli P, Fuglsang-Frederiksen A, et al. Myofascial trigger points are very prevalent in patients with chronic tension-type headache: a double-blinded controlled study. Clinical Journal of Pain. 2007;23(1):23-27. [pmid: 17277641].
Critchley D J, Ratcliffe J, Noonan S, et al. Effectiveness and Cost-Effectiveness of Three Types of Physiotherapy Used to Reduce Chronic Low Back Pain Disability: A Pragmatic Randomized Trial With Economic Evaluation. Spine. 2007;32(14):1474-1481. [pmid: 17572614].
Cunha A C, Burke T N, Franca F J, et al. Effect of global posture reeducation and of static stretching on pain, range of motion, and quality of life in women with chronic neck pain: a randomized clinical trial. Clinics (Sao Paulo, Brazil.). 2008;63(6):763-770.
Curtis P, Carey T S, Evans P, et al. Training primary care physicians to give limited manual therapy for low back pain: patient outcomes. Spine. 2000;25(22):2954-2960. [pmid: 11074684].
De Laat A, Stappaerts K, Papy S. Counseling and physical therapy as treatment for myofascial pain of the masticatory system. Journal of Orofacial Pain. 2003;17(1):42-49. [pmid: 12756930].
De Hertogh W, Vaes P, Devroey D, et al. Preliminary results, methodological considerations and recruitment difficulties of a randomised clinical trial comparing two treatment regimens for patients with headache and neck pain. BMC Musculoskeletal Disorders. 2009;10(1). Article Number: 115.Date of Publication: 2009. 2009;(1):.
Delitto A, Cibulka M T, Erhard R E, et al. Evidence for use of an extension-mobilization category in acute low back syndrome: a prescriptive validation pilot study. Phys Ther. 1993;73(4):216-222. [pmid: 8456141].
Descarreaux M, Blouin J S, Drolet M, et al. Efficacy of preventive spinal manipulation for chronic low-back pain and related disabilities: a preliminary study. Journal of Manipulative & Physiological Therapeutics. 2004;27(8):509-514. [pmid: 15510094].
Donchin M, Woolf O, Kaplan L, et al. Secondary prevention of low-back pain: A clinical trial. Spine. 1990;15(DEC):1317-1320. [pmid: 2149210].
Donkin RD, Parkin-Smith GF, Gomes AN. Possible Effect of Chiropractic Manipulation and Combined Manual Traction and Manipulation on Tension-Type Headache: A Pilot Study. Journal of the Neuromusculoskeletal System. FAL. 2002;10(3):89-97.
Doran D, Newell D. Manipulation in treatment of low back pain: a multicentre study. British Medical Journal. 1975;2(APR):161-164. [pmid: 123815].
Du D. Treatment of prolapse of lumbar intervertebral disc by tuina massotherapy combined with oral administration of buyang huanwu tang--a report of 75 cases. Journal of Traditional Chinese Medicine. 2007;27(1):43-45. [pmid: 17393626].
Ehrlich G E. Alexander technique lessons were effective for chronic or recurrent back pain at 1 year. Evidence-Based Medicine. 2009;14(1):13. [pmid: 19181945].
Erdogmus C B, Resch K L, Sabitzer R, et al. Physiotherapy-based rehabilitation following disc herniation operation: results of a randomized clinical trial. Spine. 2007;32(19):2041-2049. [pmid: 17762803].
Erhard R E, Delitto A, Cibulka M T. Relative effectiveness of an extension program and a combined program of manipulation and flexion and extension exercises in patients with acute low back syndrome. Physical Therapy. 1994;74(12):1093-1100. [pmid: 7991650].
Ernst E. "Double-blind” chiropractic manipulation in sciatica?. [German]. MMW-Fortschritte der Medizin. 2006;148(19):24.
Evans R, Bronfort G, Nelson B, et al. Two-year follow-up of a randomized clinical trial of spinal manipulation and two types of exercise for patients with chronic neck pain. Spine. 2002;27(21):2383-2389. [pmid: 12438988].
Farhadi K, Schwebel D C, Saeb M, et al. The effectiveness of wet-cupping for nonspecific low back pain in Iran: a randomized controlled trial. Complementary Therapies in Medicine. 2009;17(1):9-15. [pmid: 19114223].
Fernandez-de-Las-Penas C, Fernandez-Carnero J, Palomeque Del, et al. Manipulative treatment vs. conventional physiotherapy treatment in whiplash injury: A randomized controlled trial. Journal of Whiplash and Related Disorders. 2004;3(2):73-90.
Fiddian J. Comparison of passive mobilization and McKenzie protocol in treatment of low back pain [abstract]. Aust J Physiother. 1986;32(3):205.
Fitz-Ritson D, Fionenkon, Salansky N. Efficacy of Low Energy Laser Therapy for Extensor Neck Muscles and Sleep Pattern Improvement After “Whiplash” Injury. Journal of Manipulative and Physiological Therapeutics. MAY. 1994;17(4):277-278.
Flora Martinez, Pecino Ivan, Sola Arnau, et al. The efficacy of acupuncture to treat lumbar pain and acute pain, in a variety of situations. Seville: Andalusian Agency for Health Technology Assessment (AETSA). 2007:107.
Forestier R, Francon A, Saint-Arromand F, et al. [Are SPA therapy and pulsed electromagnetic field therapy effective for chronic neck pain? Randomised clinical trial First part: clinical evaluation]. [French]. Annales de Readaptation et de Medecine Physique. 2007;50(3):140-147. [pmid: 17229483].
Fritz J M, Delitto A, Erhard R E. Comparison of classification-based physical therapy with therapy based on clinical practice guidelines for patients with acute low back pain: a randomized clinical trial. Spine. 2003;28(13):1363-1371. [pmid: 12838091].
Gam A N, Warming S, Larsen L H, et al. Treatment of myofascial trigger-points with ultrasound combined with massage and exercise--a randomised controlled trial. Pain. 1998;77(1):73-79. [pmid: 9755021].
Gatchel R J, Polatin P B, Noe C, et al. Treatment- and cost-effectiveness of early intervention for acute low-back pain patients: A one-year prospective study. Journal of Occupational Rehabilitation. 2003;13(1):1-9. [pmid: 12611026].
Gemmell H A, Jacobson B H. The immediate effect of activator vs. meric adjustment on acute low back pain: A randomized controlled trial. Journal of Manipulative and Physiological Therapeutics. 1995;18(7):453-456. [pmid: 8568427].
George S Z, Fritz J M, Childs J D, et al. Sex differences in predictors of outcome in selected physical therapy interventions for acute low back pain. Journal of Orthopaedic & Sports Physical Therapy. 2006;36(6):354-363. [pmid: 16776485].
Ghia J N, Mao W, Toomey T C, et al. Acupuncture and chronic pain mechanisms. Pain. 1976;2(3):285-299. [pmid: 141020].
Ghroubi S, Elleuch H, Baklouti S, et al. [Chronic low back pain and vertebral manipulation]. [French]. Annales de Readaptation et de Medecine Physique. 2007;50(7):570-576. [pmid: 17382426].
Gibson T, Grahame R, Harkness J, et al. Controlled comparison of short-wave diathermy treatment with osteopathic treatment in non-specific low back pain. Lancet. 1985;1(8440):1258-1261. [pmid: 2860453].
Ginsberg F, Famaey J P. A double-blind study of topical massage with Rado-Salil ointment in mechanical low-back pain. Journal of International Medical Research. 1987;15(3):148-153. [pmid: 2956140].
Glover J R, Morris JG. Khosla. Back pain: a randomised clinical trial of rotational manipulation of the trunk. British Journal Industrial Medicine. 1974;31(1):59-64.
Godfrey C M, Morgan P P, Schatzker J. A randomized trial of manipulation for low-back pain in a medical setting. Spine. 1984;9(3):301-304. [pmid: 6233718].
Goldby L J, Moore A P, Doust J, et al. A randomized controlled trial investigating the efficiency of musculoskeletal physiotherapy on chronic low back disorder. [see comment]. Spine. 2006;31(10):1083-1093. [pmid: 16648741].
Gonzalez-Iglesias J, Fernandez-de-Las-Penas C, Cleland J A, et al. Inclusion of thoracic spine thrust manipulation into an electro-therapy/thermal program for the management of patients with acute mechanical neck pain: a randomized clinical trial. Manual Therapy. 2009;14(3):306-313. [pmid: 18692428].
Grunnesjo M I, Bogefeldt J P, Svardsudd K F, et al. A randomized controlled clinical trial of stay-active care versus manual therapy in addition to stay-active care: functional variables and pain. Journal of Manipulative & Physiological Therapeutics. 2004;27(7):431-441. [pmid: 15389174].
Gudavalli M R, Cambron J A, McGregor M, et al. A randomized clinical trial and subgroup analysis to compare flexion-distraction with active exercise for chronic low back pain. European Spine Journal. 2006;15(7):1070-1082. [pmid: 16341712].
Gudavalli M R, Jedlicka J, McGregor M, et al. A randomized clinical trial comparing flexion-distraction with active exercise for chronic low back pain: a feasibility study [Platform presentation at the Association Of Chiropractic Colleges' Eleventh Annual Conference, 2004]. J Chiropr Edu. 2004;18(1):11-12.
Haas M, Sharma R, Stano M. Cost-effectiveness of medical and chiropractic care for acute and chronic low back pain. Journal of Manipulative & Physiological Therapeutics. 2005;28(8):555-563. [pmid: 16226622].
Hackett G I, Seddon D, Kaminski D. Electroacupuncture compared with paracetamol for acute low back pain. Practitioner. 1988;232(1443):163-164. [pmid: 2973008].
Hakkinen A, Salo P, Tarvainen U, et al. Effect of manual therapy and stretching on neck muscle strength and mobility in chronic neck pain. Journal of Rehabilitation Medicine. 2007;39(7):575-579. [pmid: 17724558].
Hall T, Chan H T, Christensen L, et al. Efficacy of a C1-C2 self-sustained natural apophyseal glide (SNAG) in the management of cervicogenic headache. Journal of Orthopaedic & Sports Physical Therapy. 2007;37(3):100-107. [pmid: 17416124].
Harbach H, Moll B, Boedeker R H, et al. Minimal immunoreactive plasma beta-endorphin and decrease of cortisol at standard analgesia or different acupuncture techniques. European Journal of Anaesthesiology. 2007;24(4):370-376. [pmid: 17156512].
Harte AA, Baxter GD, Gracey JH. The effectiveness of motorised lumbar traction in the management of LBP with lumbo sacral nerve root involvement: a feasibility study. BMC Musculoskeletal Disorders. 2007;8:118. 2007.118, 2007. [pmid: 18047650].
Haugh L. Prediction of Occupational Disability From Low Back Pain For Patients of a Chiropractic Clinic. Journal of Manipulative and Physiological Therapeutics. MAY. 1994;17(4):279-280.
Hawk C, Long C R. Use of a pilot to refine the design of a study to develop a manual placebo treatment. JNMS: Journal of the Neuromusculoskeletal System. Summer. 2000;8(2):39-48. (46 ref) 2000;(2):39-48.
Hay E M, Mullis R, Lewis M, et al. Comparison of physical treatments versus a brief pain-management programme for back pain in primary care: a randomised clinical trial in physiotherapy practice. [see comment]. Lancet. 2005;365(9476):2024-2030. [pmid: 15950716].
He C, Chen P, Wang X, et al. The clinical effect of herbal magnetic corsets on lumbar disc herniation. Clinical Rehabilitation. 2006;20(12):1058-1065. [pmid: 17148517].
Helewa A, Goldsmith C H, Smythe H A, et al. Effect of therapeutic exercise and sleeping neck support on patients with chronic neck pain: a randomized clinical trial. Journal of Rheumatology. 2007;34(1):151-158. [pmid: 17216683].
Hiemeyer K, Long C. [Chiropractic manipulation, physical therapy and standardized recommendations for low back pain]. [German]. Forschende Komplementarmedizin. 1999;6(3):159-161. [pmid: 10490341].
Hoving J L, Koes B W, de Vet H C, et al. Manual therapy, physical therapy, or continued care by a general practitioner for patients with neck pain. A randomized, controlled trial.[see comment][summary for patients in Ann Intern Med. 2002 May 21;136(10):I36; PMID: 12020157]. Annals of Internal Medicine. 2002;136(10):713-722. [pmid: 12020139].
Hoving J L, Korthals-de Bos I, De Vet H, et al. The effects and costs of manual therapy, physiotherapy and treatment by the general practitioner in neck disorders: A randomized clinical experiment. [Dutch]. Huisarts.en Wetenschap. 2004;47(5):218-226.
Howe D H, Newcombe R G, Wade M T. Manipulation of the cervical spine--a pilot study. Journal of the Royal College of General Practitioners. 1983;33(254):574-579. [pmid: 6355460].
Hsieh R L, Lee W C. Are the effects of botulinum toxin injection on myofascial trigger points placebo effects or needling effects?. [comment]. Archives of Physical Medicine & Rehabilitation. 2008;89(4):792-793. [pmid: 18374016].
Hurwitz E L, Morgenstern H, Harber P, et al. Second prize: The effectiveness of physical modalities among patients with low back pain randomized to chiropractic care: findings from the UCLA low back pain study [randomized controlled trial]. J Manipulative Physiol Ther. 2002;25(1):10-20. [pmid: 11898014].
Jarzem P F, Harvey E J, Arcaro N, et al. Transcutaneous electrical nerve stimulation [TENS] for chronic low back pain. Journal of Musculoskeletal Pain. 2005;13(2):3-9.
Jing F-J, Zhang J. Clinical effect of Yi-Nao manipulation in the treatment of cervical spondylosis of vertebral artery type. [Chinese]. Chinese Journal of Clinical Rehabilitation. 2006;10(39):27-29.
Jordan A, Bendix T, Nielsen H, et al. Intensive training, physiotherapy, or manipulation for patients with chronic neck pain. A prospective, single-blinded, randomized clinical trial. [see comment]. Spine. 1998;23(3):311-318. [pmid: 9507618].
Juni P, Battaglia M, Nuesch E, et al. A randomised controlled trial of spinal manipulative therapy in acute low back pain. Annals of the Rheumatic Diseases. 2009;68(9):1420-1427. Date of Publication: September 2009. 2009;(9):1420-1427. [pmid: 18775942].
Karlberg M, Magnusson M, Malmstrom E M, et al. Postural and symptomatic improvement after physiotherapy in patients with dizziness of suspected cervical origin. Arch Phys.Med Rehabil. 1996;77(9):874-882. [pmid: 8822677].
Keller T S, Colloca C J. Mechanical force spinal manipulation increases trunk muscle strength assessed by electromyography: a comparative clinical trial. [see comment]. Journal of Manipulative & Physiological Therapeutics. 2000;23(9):585-595. [pmid: 11145798].
Khoury M A, Deall A J. A comparative study to determine the most effective chiropractic treatment protocol in the management of cervicogenic headache. symposium proceedings of the World Federation of Chiropractic 6th Biennial Congress. Paris, France. 21-26 May 2001. European Journal of Chiropractic. 2002;49(1):104-5. 2002;(1):104-105.
Kilpikoski S, Alen M, Paatelma M, et al. Outcome comparison among working adults with centralizing low back pain: Secondary analysis of a randomized controlled trial with 1-year follow-up. Advances in Physiotherapy. 2009;11(4):210-217. Date of Publication: 2009. 2009;(4):210-217.
Koes B W, Bouter L M, Knipshild P G, et al. The effectiveness of manual therapy, physiotherapy and continued treatment by the general practitioner for chronic nonspecific back and neck complaints: design of a randomized clinical trial. Journal of Manipulative & Physiological Therapeutics. 1991;14(9):498-502. [pmid: 1837047].
Koes B W, Bouter L M, van Mameren H, et al. The effectiveness of manual therapy, physiotherapy, and treatment by the general practitioner for nonspecific back and neck complaints. A randomized clinical trial. [see comment]. Spine. 1992;17(1):28-35. [pmid: 1531552].
Kogstad O A, Karterud S, Gudmundsen J. [Cervicobrachialgia. A controlled trial with conventional therapy and manipulation]. Tidsskr.Nor.Laegeforen. 1978;98(16):845-848. [pmid: 354088].
Kou W T. The effects of low-energy laser in the auriculotherapy in individuals with chronic low back pain. Dissertation Abstracts International. 1991;52(4):1946.
Kovacs F M, Llobera J, Abraira V, et al. Effectiveness and cost-effectiveness analysis of neuroreflexotherapy for subacute and chronic low back pain in routine general practice: a cluster randomized, controlled trial. Spine. 2002;27(11):1149-1159. [pmid: 12045510].
Kvorning N, Holmberg C, Grennert L, et al. Acupuncture relieves pelvic and low-back pain in late pregnancy. Acta Obstetricia et Gynecologica Scandinavica. 2004;83(3):246-250. [pmid: 14995919].
Lawrence D J, Dziedzic K. Manual therapy or pulsed shortwave diathermy provide no additional benefit over advice and exercise in the treatment of neck disorders. Focus on Alternative and Complementary Therapies. 2005;10(4):307-308.
Learman K E. Treatment effects of spinal manipulation on proprioception in subjects with chronic low back pain. 2007.
Lenehan K L, Fryer G, Mclaughlin P. The effect of muscle energy technique on gross trunk range of motion. Journal of Osteopathic Medicine. APR. 2003;6(1):13-18.
Levoska S, Keinanen-Kiukaanniemi S. Active or passive physiotherapy for occupational cervicobrachial disorders? A comparison of two treatment methods with a 1-year follow-up. Archives of Physical Medicine & Rehabilitation. 1993;74(4):425-430. [pmid: 8466426].
Lewis J S, Hewitt J S, Billington L, et al. A randomized clinical trial comparing two physiotherapy interventions for chronic low back pain. Spine. 2005;30(7):711-721. [pmid: 15803071].
Li D-J, Wang J, Gao Q, et al. Treatment of lubar intervertebral disc protrusion with traction and back stretch press manipulation of lumbar spine alone or combined with extradural injection. [Chinese]. Journal of Clinical Rehabilitative. Tissue Engineering Research. 2007;11(30):5892-5895.
Licciardone J C, Stoll S T, Fulda K G, et al. Osteopathic manipulative treatment for chronic low back pain: a randomized controlled trial. Spine. 2003;28(13):1355-1362. [pmid: 12838090].
Linde K, Witt C M, Streng A, et al. The impact of patient expectations on outcomes in four randomized controlled trials of acupuncture in patients with chronic pain. [see comment]. Pain. 2007;128(3):264-271. [pmid: 17257756].
Lindstrom I. Manual therapy and exercise therapy in patients with chronic low back pain. A randomized, controlled trial with 1-year follow-up: Point of view. Spine. 2003;28(6):531-532.
Liu Z. [Botulinum toxin A (BTX-A) point injection for treatment of the third lumbar transverse process syndrome]. [Chinese]. Zhongguo Zhenjiu. 2008;28(5):337-339.
Lopacz S, Gralewski Z. [A trial of assessment of the results of acupuncture or suggestion in the treatment of low back pain]. Neur Neurochri Pol. 1979;13(4):405-409.
Lu M, Cao D M, Zhao Y J. Clinical observation on therapeutic effect of finger-pressure therapy on prolapse of lumbar intervertebral disk] (in Chinese). [Chinese Acupuncture & Moxibustion]. 2004;24(1):25-27.
Maigne J-Y. Immediate effects of thoracic manipulation in patients with neck pain: A randomized clinical trial. Manual Therapy. 2007;12(1):e1. [pmid: 16621668].
Manniche C, Hesselsoe G, Bentzen L, et al. Clinical trial of intensive muscle training for chronic low back pain. Lancet. 1988;2(8626-8627):1473-1476. [pmid: 2904582].
Manniche C, Lundberg E, Christensen I, et al. Intensive dynamic back exercises for chronic low back pain: a clinical trial. Pain. 1991;47(1):53-63. [pmid: 1837606].
Martensson L, Stener-Victorin E, Wallin G. Acupuncture versus subcutaneous injections of sterile water as treatment for labour pain. Acta Obstetricia et Gynecologica Scandinavica. 2008;87(2):171-177. [pmid: 18231884].
Mayor E E, Perez G L, Martin Y P, et al. Randomised clinical trial for primary care patients with neck pain: Manual therapy versus electrical stimulation. [Spanish]. Atencion Primaria. 2008;40(7):337-343. [pmid: 18620635].
McKinney L. Early mobilization and outcome in acute sprains of the neck. British Medical Journal. 1989;(299):1006-1008. [pmid: 2511939].
McReynolds T M, Sheridan B J. Intramuscular ketorolac versus osteopathic manipulative treatment in the management of acute neck pain in the emergency department: A randomized clinical trial. Journal of the American Osteopathic Association. 2005;105(2):57-68. [pmid: 15784928].
Mealy K, Brennan H, Fenelon GCC. Early mobilisation of acute whiplash injuries. BMJ. 1986:292656-657.
Mellin G, HÃ¤ rkÃ¤, pÃ¤ Ã¤ K, et al. A controlled study on the outcome of inpatient and outpatient treatment of low back pain. Part IV. Long-term effects on physical measurements. Scandinavian Journal Rehabilitation Medicine. 1990;22(4):189-194.
Melzack R, Jeans M E, Stratford J G, et al. Ice massage and transcutaneous electrical stimulation: comparison of treatment for low-back pain. Pain. 1980;9(2):209-217. [pmid: 6450393].
Melzack R, Vetere P, Finch L. Transcutaneous electrical nerve stimulation for low back pain. A comparison of TENS and massage for pain and range of motion. Physical Therapy. 1983;63(4):489-493. [pmid: 6220415].
Metcalfe S, Reese H, Sydenham R. The Effect of High-Velocity Low-Amplitude Manipulation on Cervical Spine Muscle Strength: A Randomized Clinical Trial. Orthopaedic Division Review. 2007;2007(4):31-37.
Miyakoshi N, Shimada Y, Kasukawa Y, et al. Total dorsal ramus block for the treatment of chronic low back pain: a preliminary study. Joint, Bone, Spine: Revue du Rhumatisme. 2007;74(3):270-274.
Mohseni-Bandpei M A. Chronic Low Back Pain: a Randomised Controlled Trial of Spinal Manipulation Measuring Pain, Functional Disability, Lumbar Movements and Muscle Endurance Using Surface Electromyography. Cochrane. 2000.
Moodley M, Brantingham J W. The relative effectiveness of spinal manipulation and ultrasound in mechanical pain: pilot study. Journal of Chiropractic Medicine. Dec. 2002;1(4):184-8. (14 ref) 2002;(4):184-188. [pmid: 19674582].
Mu J P, Cheng J M, Ao J B, et al. [Clinical Observation on Treatment of Lumbar Intervertebral Disc Herniation with Electroacupuncture on Jiaji (Ex-B 2) Points plus Traction: A Clinical Report of 30 Cases](in Chinese). Zhen Jiu Tui Na Yi Xue. 2007;5(1):44-47.
Myers S S, Phillips R S, Davis R B, et al. Patient expectations as predictors of outcome in patients with acute low back pain. Journal of General Internal Medicine. 2008;23(2):148-153. [pmid: 18066631].
Naumann J, Holland J, Guethlin C, et al. Effectiveness of an automatic over-water massage device in back pain - an RCT. Focus on Alternative and Complementary Therapies. 2004;36(9):36.
Niemisto L, Sarna S, Lahtinen-Suopanki T, et al. Predictive factors for 1-year outcome of chronic low back pain following manipulation, stabilizing exercises, and physician consultation or physician consultation alone. Journal of Rehabilitation Medicine. 2004;36(3):104-109. [pmid: 15209452].
Nilsson N. A randomized controlled trial of the effect of spinal manipulation in the treatment of cervicogenic headache. [see comment]. Journal of Manipulative & Physiological Therapeutics. 1995;18(7):435-440. [pmid: 8568424].
Nyiendo J, Haas M, Goodwin P. Patient characteristics, practice activities, and one-month outcomes for chronic, recurrent low-back pain treated by chiropractors and family medicine physicians: a practice-based feasibility study. Journal of Manipulative & Physiological Therapeutics. 2000;23(4):239-245. [pmid: 10820296].
Nyiendo J, Haas M, Goldberg B, et al. Pain, disability, and satisfaction outcomes and predictors of outcomes: a practice-based study of chronic low back pain patients attending primary care and chiropractic physicians. Journal of Manipulative & Physiological Therapeutics. 2001;24(7):433-439. [pmid: 11562650].
Ongley M J, Klein R G, Dorman T A, et al. A new approach to the treatment of chronic low back pain. Lancet. 1987;2(8551):143-146. [pmid: 2439856].
Oostendorp R. A Preliminary Report on the Use of the Propriosensory Facilitating Method Versus the Williams Method in the Treatment of Patients with Non-Specific Low Back Pain. Manual Medicine. 1988;3(3):106-109.
Ostelo R W J G. Soft tissue manipulation, exercise and education improve pain and disability in patients with non-specific low back pain. Australian Journal of Physiotherapy. 2000;46(4):316.
Ouseley B R, Parkin-Smith G F. Possible effects of chiropractic spinal manipulation and mobilization in the treatment of chronic tension-type headache: a pilot study. European Journal of Chiropractic. 2002;50(1):3-13.
Palmgren P J, Sandstrom P J, Lundqvist F J, et al. Improvement after chiropractic care in cervicocephalic kinesthetic sensibility and subjective pain intensity in patients with nontraumatic chronic neck pain.[erratum appears in J Manipulative Physiol Ther. 2006 May;29(4):340]. Journal of Manipulative & Physiological Therapeutics. 2006;29(2):100-106. [pmid: 16461168].
Persson L C, Lilja A. Pain, coping, emotional state and physical function in patients with chronic radicular neck pain. A comparison between patients treated with surgery, physiotherapy or neck collar--a blinded, prospective randomized study. Disabil.Rehabil. 2001;23(8):325-335. [pmid: 11374522].
Pesco M S, Chosa E, Tajima N. Comparative study of hands-on therapy with active exercises vs education with active exercises for the management of upper back pain. Journal of Manipulative & Physiological Therapeutics. 2006;29(3):228-235. [pmid: 16584949].
Pfefer MT, Cooper SR, Menke JM. Comparison of mechanical force, manually assisted activator manipulation versus manual side-posture high-velocity, low-amplitude manipulation in patients with low back pain: A randomized pilot study. J Chiropr Educ. 2006;20(1):90.
Rannou F. Two types of spinal manipulations and minimal conservative medical care for older adults with subacute or chronic low back pain of a very low level intensity. Focus on Alternative and Complementary Therapies. 2009;14(4):316-317. Date of Publication: December 2009. 2009;(4):316-317.
Rasmussen-Barr E, Nilsson-Wikmar L, Arvidsson I. Stabilizing training compared with manual treatment in sub-acute and chronic low-back pain. Manual Therapy. 2003;8(4):233-241. [pmid: 14559046].
Riipinen M, Niemisto L, Lindgren K A, et al. Psychosocial differences as predictors for recovery from chronic low back pain following manipulation, stabilizing exercises and physician consultation or physician consultation alone. Journal of Rehabilitation Medicine. 2005;37(3):152-158. [pmid: 16040472].
Rittweger J, Just K, Kautzsch K, et al. Treatment of chronic lower back pain with lumbar extension and whole-body vibration exercise: a randomized controlled trial. Spine. 2002;27(17):1829-1834. [pmid: 12221343].
Santilli V, Beghi E, Finucci S. Chiropractic manipulation in the treatment of acute back pain and sciatica with disc protrusion: a randomized double-blind clinical trial of active and simulated spinal manipulations. Spine Journal: Official Journal of the North American Spine Society. 2006;6(2):131-137.
Savolainen A, Ahlberg J, Nummila H, et al. Active or passive treatment for neck-shoulder pain in occupational health care? A randomized controlled trial. Occupational Medicine. 2004;54(6):422-424. [pmid: 15358840].
Schellingerhout J M, Verhagen A P, Heymans M W, et al. Which subgroups of patients with non-specific neck pain are more likely to benefit from spinal manipulation therapy, physiotherapy, or usual care?. Pain. 2008;139(3):670-680. [pmid: 18774225].
Schwerla F, Bischoff A, Nurnberger A, et al. Osteopathic treatment of patients with chronic nonspecific neck pain: A randomised controlled trial of efficacy. Forschende Komplementarmedizin. 2008;15(3):138-145. [pmid: 18617745].
Sherman K J, Hogeboom C J, Cherkin D C, et al. Description and validation of a non-invasive placebo acupuncture procedure. [see comment]. Journal of Alternative & Complementary Medicine. 2002;8(1):11-19.
Simons D G, Dommerholt J. Botulinum toxin A versus bupivacaine trigger point injections for the treatment of myofascial pain syndrome: A randomized double blind crossover study: C.L. Graboski, D.S. Gray, R.S. Burnham, Pain 118: 170-175, 2005 - Commentary. Journal of Musculoskeletal Pain. 2006;14(2):59-60.
Sims-Williams H, Jayson M, Young S, et al. Controlled trial of mobilisation and manipulation for patients with low back pain in general practice. British Medical Journal. 1978;2(NOV):1338-1340. [pmid: 152663].
Snyder B J, Zhang J. Low-force chiropractic adjustments on acute and chronic low back pain. The Journal of Chiropractic Education. 2005;19(SPR):71-72.
Srbely J Z, Dickey J P. Randomized controlled study of the antinociceptive effect of ultrasound on trigger point sensitivity: novel applications in myofascial therapy?. Clinical Rehabilitation. 2007;21(5):411-417. [pmid: 17613561].
Stanton W R, Jull G A. Cervicogenic headache: locus of control and success of treatment. Headache. 2003;43(9):956-961. [pmid: 14511272].
Storheim K. Spina manipulative therapy for low back pain is effective only when compared to sham or ineffective treatments. Australian Journal of Physiotherapy. 2004;50(2):115. 2004. [pmid: 15252950].
Sturge R, Bulstrode F. Low back pain: Comparison of chiropractic and hospital outpatient treatment (VI). British Medical Journal. 1990;300(6740):1648-1649.
Suen L K, Wong T K, Chung J W, et al. Auriculotherapy on low back pain in the elderly. Complementary Therapies in Clinical Practice. 2007;13(1):63-69. [pmid: 17210513].
Unlu Z, Tasci S, Tarhan S, et al. Comparison of 3 physical therapy modalities for acute pain in lumbar disc herniation measured by clinical evaluation and magnetic resonance imaging. J Manipulative Physiol Ther. 2008;31(3):191-198. [pmid: 18394495].
Vas J, Aguilar I, Campos M A, et al. Randomised controlled study in the primary healthcare sector to investigate the effectiveness and safety of auriculotherapy for the treatment of uncomplicated chronic rachialgia: a study protocol. BMC Complementary and Alternative Medicine. 2008;836.
Walker M J, Boyles R E, Young B A, et al. The effectiveness of manual physical therapy and exercise for mechanical neck pain: a randomized clinical trial. Spine. 2008;33(22):2371-2378. [pmid: 18923311].
Wand B M, Bird C, McAuley J H, et al. Early intervention for the management of acute low back pain: a single-blind randomized controlled trial of biopsychosocial education, manual therapy, and exercise. Spine. 2004;29(21):2350-2356. [pmid: 15507794].
Wang B, Wu J-X, Wang J. Active exercise and massage for non-specific low back pain: A clinical randomized controlled trial. [Chinese]. Chinese Journal of Clinical Rehabilitation. 2005;9(10):1-3.
Wang C-H, Ci H-F, Gao Q, et al. [Observation on the effect of silver needle therapy in the treatment of failed back surgery syndrome]. Zhongguo Linchuang Kangfu. 2004;8(11):2082-2083.
Wang G, Qu F. Treatment of 482 cases of cervical spondylopathy by combining point-injection and needle-warming via moxibustion. J Tradit.Chin.Med. 2001;21(1):31-33. [pmid: 11360535].
Waterworth R F, Hunter I A. An open study of diflunisal, conservative and manipulative therapy in the management of acute mechanical low back pain. New Zealand Medical Journal. 1985;98(779):372-375. [pmid: 3157894].
Wedenberg K, Moen B, Norling A. A prospective randomized study comparing acupuncture with physiotherapy for low-back and pelvic pain in pregnancy. Acta Obstetricia et Gynecologica Scandinavica. 2000;79(5):331-335. [pmid: 10830757].
Weiss H R, Heckel I, Stephan C. Application of passive transverse forces in the rehabilitation of spinal deformities: a randomized controlled study. Studies in Health Technology & Informatics. 2002;88:304-8. 2002.304-308. [pmid: 15456051].
Westaway M. Manual therapy, physical therapy, or care by a general practitioner for neck pain. Clinical Journal of Sport Medicine. 2003;13(3):197. [pmid: 12795301].
Whitehurst D G T, Lewis M, Yao G L, et al. A brief pain management program compared with physical therapy for low back pain: Results from an economic analysis alongside a randomized clinical trial. Arthritis Care and Research. 2007;57(3):466-473. [pmid: 17394176].
Whitman J M, Flynn T W, Childs J D, et al. A comparison between two physical therapy treatment programs for patients with lumbar spinal stenosis: a randomized clinical trial. [see comment]. Spine. 2006;31(22):2541-2549. [pmid: 17047542].
Whittingham W, Dacosta C, McCrossin P, et al. Randomized, placebo-controlled clinical trial of the efficacy of chiropractic treatment for chronic cervicogenic headaches. symposium proceedings of the World Federation of Chiropractic 6th Biennial Congress. Paris, France. 21-26 May 2001. European Journal of Chiropractic. 2002;49(1):109-10. 2001;(1):109-110.
Wilkey A S, McCarthy P W, Byfield D, et al. A National Health Service hospital-based study of the relative effectiveness of chiropractic manipulative treatment compared to normal outpatient pain clinic protocols in the management of chronic mechanical low back pain: a pilot study for a randomized clinical trial. European Journal of Chiropractic. 2003;51(2):125-126.
Wilkey A, Gregory M, Byfield D, et al. A comparison between chiropractic management and pain clinic management for chronic low-back pain in a national health service outpatient clinic. Journal of Alternative and Complementary Medicine. 2008;14(5):465-473.
Wilkey A S, McCarthy P W, Byfield D, et al. Chiropractic management compared with outpatient pain clinic management for chronic mechanical low back pain: a hospital-based, pilot study. Focus on Alternative and Complementary Therapies. DEC. 2003;8(4):488.
Williams N H, Wilkinson C, Russell I, et al. Randomized osteopathic manipulation study (ROMANS): pragmatic trial for spinal pain in primary care. Family Practice. 2003;20(6):662-669. [pmid: 14701889].
Wonderling D. Acupuncture in mainstream health care. [comment]. BMJ. 2006;333(7569):611-612. [pmid: 16990295].
Wood T G, Colloca C J, Matthews R. A pilot randomized clinical trial on the relative effect of instrumental (MFMA) versus manual (HVLA) manipulation in the treatment of cervical spine dysfunction. Journal of Manipulative & Physiological Therapeutics. 2001;24(4):260-271. [pmid: 11353937].
Wu J-X, Wang B. Early intervention of aerobic exercise to rehabilitation of non-specific low back pain. Chinese Journal of Clinical Rehabilitation. 2004;8(26):5718-5720.
Yip Y B, Tse S H. An experimental study on the effectiveness of acupressure with aromatic lavender essential oil for sub-acute, non-specific neck pain in Hong Kong. Complementary Therapies in Clinical Practice. 2006;12(1):18-26. [pmid: 16401526].
Yip Y B, Tse H M, Wu K K. An experimental study comparing the effects of combined transcutaneous acupoint electrical stimulation and electromagnetic millimetre waves for spinal pain in Hong Kong. Complementary Therapies in Clinical Practice. 2007;13(1):4-14. [pmid: 17210506].
Yoon S H, Rah U W, Sheen S S, et al. Comparison of 3 needle sizes for trigger point injection in myofascial pain syndrome of upper- and middle-trapezius muscle: a randomized controlled trial. Archives of Physical Medicine & Rehabilitation. 2009;90(8):1332-1339. [pmid: 19651267].
Yu F, Morgenstern H, Hurwitz E, et al. Use of a Markov transition model to analyse longitudinal low-back pain data. Statistical Methods in Medical Research. 2003;12(4):321-331. [pmid: 12939099].
Zhang J, Enix D, Snyder B, et al. Effects of Biofreeze and chiropractic adjustments on acute low back pain: a pilot study. J Chiropractic Med. 2008;7(2):59-65.
Zhang S-Q, Wang Z, Wang H-L. Analgesia of “three points and five methods” therapy on radiculalgia in protrusion of lumbar intervertebral disc. Chinese Journal of Clinical Rehabilitation. 2005;9(26):226-227.
Zylbergold R S, Piper M C. Lumbar disc disease: comparative analysis of physical therapy treatments. Archives of Physical Medicine & Rehabilitation. 1981;62(4):176-179. [pmid: 6453571].

## Not Limited to Single Region or Treatment of Other Body Parts

Aguilera F J, Martin D P, Masanet R A, et al. Immediate effect of ultrasound and ischemic compression techniques for the treatment of trapezius latent myofascial trigger points in healthy subjects: a randomized controlled study. Journal of Manipulative & Physiological Therapeutics. 2009;32(7):515-520. [pmid: 19748402].
Burton A K, Tillotson K M, Cleary J. Single-blind randomised controlled trial of chemonucleolysis and manipulation in the treatment of symptomatic lumbar disc herniation. European Spine Journal. 2000;9(3):202-207. [pmid: 10905437].
Chen H W, Yao L J, Tang Y C. [Observations on the efficacy of horizontal needling with sticking of needle and flicking for treating 102 patients with scapular, dorsal and lumbar myofascitis](in Chinese). [Shanghai Journal of Acupuncture and Moxibustion]. 2006;25(5):26-27.
Clements B, Gibbons. The Amelioration of Atlanto-Axial Rotation Asymmetry Using High Velocity Low Amplitude Manipulation: Is the Direction of Thrust Important?. Journal of Osteopathic Medicine. APR. 2001;4(1):8-14.
Coxhead C, Inskip H, Mead T, et al. Multicentre trial of physiotherapy in the management of sciatic symptoms. Lancet. 1981;1(MAY):1065-1068. [pmid: 6112444].
Endres H G, Zenz M, Schaub C, et al. [German Acupuncture Trials (gerac) address problems of methodology associated with acupuncture studies]. [see comment][erratum appears in Schmerz. 2005 Aug;19(4):333]. [German]. Schmerz. 2005;19(3):201-204. [pmid: 15959826].
Goddard G, Karibe H, McNeill C, et al. Acupuncture and sham acupuncture reduce muscle pain in myofascial pain patients. Journal of Orofacial Pain. 2002;16(1):71-76. [pmid: 11889662].
Gu Z P. Clinical observations on treatment of lumbodorsal myofascitis by acupuncture plus point injection](in Chinese). [Shanghai Journal of Acupuncture and Moxibustion]. 2007;26(1):22-23.
Hansson Y, Carlsson C, Olsson E. Intramuscular and periosteal acupuncture for anxiety and sleep quality in patients with chronic musculoskeletal pain--an evaluator blind, controlled study. Acupuncture in Medicine. 2007;25(4):148-157. [pmid: 18160925].
Hansson Y, Carlsson C, Olsson E. Intramuscular and periosteal acupuncture in patients suffering from chronic musculoskeletal pain - a controlled trial. Acupuncture in Medicine. 2008;26(4):214-223. [pmid: 19098692].
Hawkinson E, Snyder B, SANDERS G. Evaluation of the Toftness System of Chiropractic Adjusting for the Relief of Acute Pain of Musculoskeletal Origin. Chiropractic Technique. MAY. 1992;4(2):57-60.
He D, Hostmark A T, Veiersted K B, et al. Effect of intensive acupuncture on pain-related social and psychological variables for women with chronic neck and shoulder pain--an RCT with six month and three year follow up. Acupuncture in Medicine. 2005;23(2):52-61. [pmid: 16025785].
He D, Veiersted K B, Hostmark A T, et al. Effect of acupuncture treatment on chronic neck and shoulder pain in sedentary female workers: a 6-month and 3-year follow-up study. [see comment]. Pain. 2004;109(3):299-307. [pmid: 15157691].
Hong C Z. Lidocaine injection versus dry needling to myofascial trigger point. The importance of the local twitch response. American Journal of Physical Medicine & Rehabilitation. 1994;73(4):256-263. [pmid: 8043247].
Hope-Allan N, Adams J, Sibbritt D, et al. The use of acupuncture in maternity care: a pilot study evaluating the acupuncture service in an Australian hospital antenatal clinic. Complementary Therapies in Nursing & Midwifery. 2004;10(4):229-232. [pmid: 15519940].
Kamanli A, Kaya A, Ardicoglu O, et al. Comparison of lidocaine injection, botulinum toxin injection, and dry needling to trigger points in myofascial pain syndrome. Rheumatology International. 2005;25(8):604-611. [pmid: 15372199].
Kluba T, Dikmenli G, Dietz K, et al. Comparison of surgical and conservative treatment for degenerative lumbar scoliosis. Archives of Orthopaedic and Trauma Surgery. 2009;129(1):1-5. [pmid: 18560848].
Lakhani E, Nook B, Haas M, et al. Motion palpation used as a postmanipulation assessment tool for monitoring end-feel improvement: a randomized controlled trial of test responsiveness. Journal of Manipulative & Physiological Therapeutics. 2009;32(7):549-555. [pmid: 19748406].
Luo J, Huang L H, Kong L S, et al. [Observation on the Therapeutic Effect of Lingnan Muscle-pricking Therapy for Treatment of Ankylosing Spondylitis] (in Chinese). [Acupuncture Research]. 2003;28(4):276-279.
Noll D R, Degenhardt B F, Stuart M, et al. Effectiveness of a Sham Protocol and Adverse Effects in a Clinical Trial of Osteopathic Manipulative Treatment in Nursing Home Patients. Journal of the American Osteopathic Association. 2004;104(3):107-113+101. [pmid: 15083985].
Santiesteban A. Comparison of Electroacupuncture and Selected Physical Therapy for Acute Spine Pain. American Journal of Acupuncture. 2000;(12):257-262.
Shen Y F, Goddard G. The short-term effects of acupuncture on myofascial pain patients after clenching. Pain Practice. 2007;7(3):256-264. [pmid: 17714105].
Skargren E I, Oberg B E. Predictive factors for 1-year outcome of low-back and neck pain in patients treated in primary care: comparison between the treatment strategies chiropractic and physiotherapy. Pain. 1998;77(2):201-207. [pmid: 9766838].
Skargren E I, Carlsson P G, Oberg B E. One-year follow-up comparison of the cost and effectiveness of chiropractic and physiotherapy as primary management for back pain. Subgroup analysis, recurrence, and additional health care utilization. Spine. 1998;23(17):1875-1883. [pmid: 9762745].
Skargren E I, Oberg B E, Carlsson P G, et al. Cost and effectiveness analysis of chiropractic and physiotherapy treatment for low back and neck pain. Six-month follow-up. Spine. 1997;22(18):2167-2177. [pmid: 9322328].
Smith P, Mosscrop D, Davies S, et al. The efficacy of acupuncture in the treatment of temporomandibular joint myofascial pain: a randomised controlled trial. Journal of Dentistry. 2007;35(3):259-267. [pmid: 17095133].
Snyder B J, Sanders G E. Evaluation of the Toftness System of Chiropractic Adjusting for subjects with chronic back pain, chronic tension headaches, or primary dysmenorrhea. Chiropractic Technique. 1996;8(1):3-9.
Sun Y Z, Chen H L. [Controlled study on Shu-Mu point combination for treatment of endometriosis]. [Chinese]. Zhongguo Zhenjiu. 2006;26(12):863-865.
Thomson O, Haig L, Mansfield H. The effects of high-velocity low-amplitude thrust manipulation and mobilisation techniques on pressure pain threshold in the lumbar spine. International Journal of Osteopathic Medicine. 2009;12(2):56-62.
Toro-Velasco C, rroyo-Morales M, Fernandez-de-Las-Penas C, et al. Short-term effects of manual therapy on heart rate variability, mood state, and pressure pain sensitivity in patients with chronic tension-type headache: a pilot study. Journal of Manipulative & Physiological Therapeutics. 2009;32(7):527-535. [pmid: 19748404].
Tuchin P J. A twelve month clinical trial of chiropractic spinal manipulative therapy for migraine. Australasian Chiropractic & Osteopathy. 1999;8(2):61-65. [pmid: 17987194].
van den, Dolder P A, Roberts D L. A trial into the effectiveness of soft tissue massage in the treatment of shoulder pain. [see comment]. Australian Journal of Physiotherapy. 2003;49(3):183-188. [pmid: 12952518].
Walach H, Guthlin C, Konig M. Efficacy of massage therapy in chronic pain: a pragmatic randomized trial. Journal of Alternative & Complementary Medicine. 2003;9(6):837-846.
Williams N, Wilkinson C, Russell I, et al. Randomised osteopathic manipulation study: a pragmatic rct based in primary care. Journal of Orthopaedic Medicine. 2003;25(1):25.
Williams S E, Penn P F, Owens E F, et al. A progress report of chiropractic efficacy in the treatment of chronic low back pain, neck pain, headaches and related peripheral conditions: a double blinded time-series study. CRJ: Chiropractic Research Journal. 1989;1(3):11-21. (3 ref) 1989;(3):11-21.
Wolfe H L. Acute Lumbar Sprain & Acupuncture. Blue Poppy Press. 2006;2006(April).
Yue S J. Acupuncture for chronic back and neck pain. Acupunct Electro Ther Res. 1978;3(3-4):323-324.
Zhang J. Chiropractic Adjustments and Orthotics Reduced Symptoms for Standing Workers. J Chiropractic Med. 2005;4(4):177-181.

## Does Not Report Relevant Outcomes

Bialosky J E, Bishop M D, Robinson M E, et al. Spinal manipulative therapy has an immediate effect on thermal pain sensitivity in people with low back pain: a randomized controlled trial. Physical Therapy. 2009;89(12):1292-1303. [pmid: 19797305].
Bialosky J E, George S Z, Bishop M D, et al. Immediate effects of spinal manipulative therapy in subjects with low back pain: a pilot study. Combined Sections Meeting. Nashville, Tennessee. February 6-9, 2008. Journal of Orthopaedic and Sports Physical Therapy. 2008. 1 Suppl. 2008;38:A13.
Ellestad S M, Nagle R V, Boesler D R, et al. Electromyographic and skin resistance responses to osteopathic manipulative treatment for low-back pain. Journal of the American Osteopathic Association. 1988;88(8):991-997. [pmid: 2975645].
Feng Y, Wei J, Gao Y, et al. Internal pressure in nucleus pulposus and compression degree of adjacent nerve roots following lumbar vertebral herniation. Chinese Journal of Clinical Rehabilitation. 2005;9(38):185-187.
Hoiriis K, McDuffie FC, Pfleger. The Results of a Randomized Controlled Clinical Trial of Chiropractic Care Versus Drug Therapy for Subacute Low Back Pain. The Journal of Chiropractic Education. SPR. 2000;14(1):38-39.
Liu Y Z. [Treatment of cervical spondylosis of vertebroarterial type with acupuncture regulating the governor vessel]. [Chinese]. Zhongguo Zhenjiu. 2007;27(4):255-257.
MacPherson H, Thorpe L, Thomas K, et al. Acupuncture for low back pain: traditional diagnosis and treatment of 148 patients in a clinical trial. Complementary Therapies in Medicine. 2004;12(1):38-44. [pmid: 15130570].
Sterling M, Pedler A, Chan C, et al. Cervical lateral glide increases nociceptive flexion reflex threshold but not pressure or thermal pain thresholds in chronic whiplash associated disorders: A pilot randomised controlled trial. Man Ther. 2010;15(2):149-153. [pmid: 19884037].
Sun D B. [Clinical observation of prolapse lumbar intervertebral disc treated by Weiyang (BL39) point inserted by acupuncture and moxibustion and massage]. Shanghai journal of acupuncture and moxibustion. 1998;17(6):12.
Yu S. The therapeutic effects of triple puncture and routine body needling for cervical spondylosis. Journal of Traditional Chinese Medicine. 2003;23(4):282-283. [pmid: 14719300].

## Other Language Not Specified in Protocol

Acupuncture relieves pelvic and low back pain in late pregnancy (n=72). Acupuncture in Medicine. 2004;22(4):223-224.
Evans R, Bronfort G, Bittell S, et al. A pilot study for a randomized clinical trial assessing chiropractic care, medical care, and self-care education for acute and subacute neck pain patients. Journal of Manipulative & Physiological Therapeutics. 2003;26(7):403-411. [pmid: 12975626].
Farasyn A, Meeusen R. Effect of roptrotherapy on pressure-pain thresholds in patients with subacute nonspecific low back pain. Journal of Musculoskeletal Pain. 2007;15(1):41-53. (59 ref) 2007;(1):41-53.
Miyazaki S, Hagihara A, Kanda R, et al. Applicability of press needles to a double-blind trial: a randomized, double-blind, placebo-controlled trial. Clinical Journal of Pain. 2009;25(5):438-444. [pmid: 19454879].
Multiple A U T H. Abstracts of ACC Conference Proceedings: Poster presentations [ACC contributed papers presented at the 2000 Association of Chiropractic Colleges Seventh Annual Conference]. J Chiropr Educ. 2000;14(1):27-56.
Ostermann T, Blaser G, Bertram M, et al. Effects of rhythmic embrocation therapy with solum oil in chronic pain patients: a prospective observational study. Clinical Journal of Pain. 2008;24(3):237-243. [pmid: 18287830].
Wiegand R A. Logan Basic Methods and Low-Force Adjusting for Treatment of Chronic Low Back Pain in the Age Group 57 and Older: A Pilot Study. The Journal of Chiropractic Education. SPR. 2003;17(1):42.

## An Irrelevant Cause of Pain or Eligible Population

Bram N L, Lamping D L, Yates R G. Effects of Chiropractic Treatment on Blood Pressure and Anxiety: a Randomized, Controlled Trial. J Manipulative Physiol Ther. 1988;11(6):484-488. [pmid: 3075649].
Brantingham J W, Globe G, Stakes N O, et al. A prospective randomized clinical trial to determine efficacy of combined spinal manipulation and patella mobilization compared to patella mobilization alone in the conservative management of patellofemoral pain syndrom [randomized controlled trial]. JACA Online. 2006;43(7):Online-18.
Bronfort G, Evans R L, Maiers M, et al. Spinal manipulation, epidural injections, and self-care for sciatica: a pilot study for a randomized clinical trial. Journal of Manipulative & Physiological Therapeutics. 2004;27(8):503-508. [pmid: 15510093].
Cottingham J, Porges S, Richmond K. Shifts in pelvic inclination angle and parasympathetic tone produced by Rolfing soft tissue manipulation. Physical Therapy. SEP. 1988;68(9):1364-1370. [pmid: 3420170].
Kessler T J, Brunner F, Kunzer S, et al. [Effects of Maitland's manual mobilization on the thoracic spine]. [German]. Rehabilitation. 2005;44(6):361-366. [pmid: 16320180].
Kohne E, Jones A, KORPORAAL C, et al. A prospective, single-blinded, randomized, controlled clinical trial of the effects of manipulation on proprioception and ankle dorsiflexion in chronic recurrent ankle sprain [randomized controlled trial]. JACA Online. 2007;44(5):Online-17.
Kreczi T, Klingler D. A comparison of laser acupuncture versus placebo in radicular and pseudoradicular pain syndromes as recorded by subjective responses of patients. Acupuncture and Electro-Therapeutics Research. 1986;11(3-4):207-216.
Krekoukias G, Petty N J, Cheek L. Comparison of surface electromyographic activity of erector spinae before and after the application of central posteroanterior mobilisation on the lumbar spine. Journal of Electromyography and Kinesiology. 2009;19(1):39-45. [pmid: 17888680].
Lee H. Promising results for acupuncture in pelvic girdle pain during pregnancy. Fact. 2005;10(3):208-209.
Mitchell U H, Wooden M J, McKeough D M. The short-term effect of lumbar positional distraction. Journal of Manual and Manipulative Therapy. 2001;9(4):213-221.
Paungmali A, O'Leary S, Souvlis T, et al. Hypoalgesic and sympathoexcitatory effects of mobilization with movement for lateral epicondylalgia. Physical Therapy. 2003;83(4):374-383. [pmid: 12665408].
Steurer J. Acute low back pain: Diclofenac and spinal manipulative therapy have no additional effect to paracetamol. [German]. Schweizerische Rundschau fur Medizin - Praxis. 2008;97(6):328-329.
Tuchin P J, Pollard H, Bonello R. A randomized controlled trial of chiropractic spinal manipulative therapy for migraine. J Manipulative Physiol Ther. 2000;23(2):91-95. [pmid: 10714533].
Wan X W. [Clinical observation on acupuncture combined with cupping therapy for treatment of ankylosing spondylitis] (in Chinese). [Chinese Acupuncture & Moxibustion]. 2005;25(8):551-552.
Wang Z, Zhang T F, Zhang H X, et al. [Clinical observation on acupoint-injection for treatment of lumbago-leg pain induced by primary osteoporosis]. Zhongguo zhen jiu = Chinese acupuncture & moxibustion. 2008;28(4):261-264.
Wolff H D. [Complications during manual therapy of the cervical spine. Supplement to H. P. Schmitt's paper: “Manual therapy in the region of the cervical spine and its dangers: ruptures and occlusions of the vertebral artery”]. [German]. ZFA.- Zeitschrift fur Allgemeinmedizin. 1978;54(8):475-479. [pmid: 636541].
Yerys S, Makofsky H, Byrd C, et al. Effect of mobilization of the anterior hip capsule on gluteus maximus strength. Journal of Manual and Manipulative Therapy. 2002;10(4):218-224.
Zundorf A. Chronic low back pain: Sham acupuncture is superior to conventional therapy. [German]. Aktuelle Rheumatologie. 2008;33(1):10-11.