# Evidence Tables

## Low Pack Pain

Table 1.1 Low Back Pain - Acupuncture – Acute/Sub-acute - Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Huang, SR (2006)1 Country: China Quality score: 4/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 8 wks Final assessments: immediately post tx N screened: 98 N randomized: 98 N completed tx: 98 N attended last fu: NR Inclusion: L4/5 Disc herniation or with other disc herniation; Age < 65 yrs; Duration of pain ≤ 2w; Non-use of glucocorticoid and nonsteroidal anti-inflammatory drugs in the study period Exclusion: pregnant/breast-feeding women; After operation; Up L3/4 Disc herniation or L5/S1 Disc herniation; syndrome; Other chronic pain diseases; Hypertension; Heart disease; Mental Pt | Mean age (SD/range): IG = 42.8 vs. CG = 46.2 yrs % of male: IG = 52.8%; CG = 46.7% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc herniation Duration of Pain: Acute ≤ 2wk, IG = 7.2 ds; CG = 6.9 ds Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 53)– local single-point E-acu: At Yaotu; 0.6ms, 15Hz, 50min/time, 2times/wk x 4- total of 9 tx Drop outs: 0 CG (n = 45) – Routing E-acu: acupuncture at Dachangyu, Guangyuanyu, Bamiu, Jiaji, Xubian, Huantiao, Fengshi, Yinmen, Weizhong, Yanglinquan, Chenshan, Kunlun; same as IG Drop outs: 0 | Outcome instruments: Pain: NA Disability: ODQ (A, B) Results: Baseline: Pain: NA Disability: NR Immediate post tx: Mean chg from A: IG = 18.7; CG = 35.65 Pain: NA Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Results: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR Summary local single-point electro-acu group is more effective than routine electro-acu group
Lai, Y (2004)2 Country: China Quality score: 3/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 20 ds Final assessments: immediately post tx N screened: Don’t know N randomized: 76 N completed tx: 76 N attended last fu: NR Eligibility criteria: inclusion: 1. Diagnostic using Chinese New Medicine Clinical Trial Reference 1993 ref[2] exclusion: Pt with server protrusion, which press the nerve | Mean age (SD/range): NR % of male: NR Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: disc/joint disease Duration of Pain: IG - 12 hr- 39 ds for whole study, It mentioned in the report as acute.; CG – 13 hr -39 ds for whole study, acute as well Severity of pain (Grading): NR NR Co-interventions: NR | Groups IG (n = 41)–Acupuncture Xi-cleft and normal points: 38mmX25-40mm needle for Xi-cleft point, retention 30min+point injection of Angelicate, 2 ml/point,; 1tx/d, 10 tx/course x 2 Drop outs: 0 CG (n = 35) – Acupuncture normal points: 38 mm x 40-75 mm needle for normal point acu, retention 30 min + point injection of Angelicate, 2 ml/point,; same as IG Drop outs: 0 | Outcomes: Pain: Pain VAS, B, pain difference from baseline Disability: NA Results: Baseline: Pain: NR Disability: NA Immediate post tx: Pain: IG = 5.63 (1.12); CG = 4.51 (0.92) Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: Well being, Chinese Standard, B Results: Immediate post tx: IG = 97.6%, CG = 85.7% improved Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: acu can relieve the pain in Pts with lumbar intervertebral disc protrusion. The effect of needling Xi-Cleft points as a main tx in cooperation with point injection is better than that of routine acu therapy in cooperation with point injection
Wen-Jun, L (2000)3 Country: China Quality score: 2/13 Initial of reviewer: SG | Trial Design RCT Tx duration: NR Final assessments: immediately post tx N screened: NR N randomized: 238 N completed tx: NR N attended last fu: NR Eligibility criteria:; - inclusion: Pts with acute lumbar sprain; - - exclusion: NR | Mean age (SD/range): 14-65 yrs % of male: 84.5% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Sprain Duration of Pain: Acute, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG1 (n = 112)– Acu-Tx: Lumbar acupoint chosen at L2-4, needles inserted perpendicular, manipulation: pushing and withdrawal, retatined for 15-20 min, after acu, moxibusion applied; 5 tx total Drop outs: NR IG2 (n = 126) – Acu-Control: needle is rapidly inserted into S16 point to 0.5-1.0 cun depth and twisted for 30-60 sec to obtain response; retain for 10-20 min; after relief of pain, the Ashi point is treated by inserting the needle to 1.5-2.5 cun depth; moxibustion given at the same site for 10-15 min; 5 tx total Drop outs: NR | Outcome instruments: Pain: NR Disability: NA Results: Baseline: NA Pain: NR Disability: NR Immediate post tx: NA Pain: NR Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Response rate Immediate post tx: IG1: 69.7% vs. IG2 94.4% p < 0.01 Short term: NR Intermediate: NR Long term: NR Harms: NR Summary of results (if provided): NA
Xing-wei (2007)4 Country: China Quality score: 3/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 15 ds Final assessments: immediately post tx N screened: NR N randomized: 78 N completed tx:78 N attended last fu: NR Inclusion: Diagnosed as lumbar herniation according to “People's Republic of China in the pharmaceutical industry standards – traditional Chinese medicine diagnostic efficacy standards”. Diagnosis verified with CT or MRI; Age < 70 Exclusion: other vertebral disc or joint disease; chronic Pts with multiple reoccurrence at remission stage; heat resistance-type | Mean age (SD/range): IG = 47 Vs. CG = 44 yrs % of male: IG = 51.3%, CG = 56.4% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: 1-disc/joint disease Duration of Pain: acute; subacute (up to 12 wks), IG = 9.7 ds; CG = 10.6 ds Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 39) – routine acu. +warming needle moxibustion: unilateral and bilateral stinulated at BL 23, GV 4, GV 3,BL 40 etc. with needles until “deqi” sensation reached ret. 30 min; 1 sess/d x 15 sess. Drop outs: A= 0 CG (n = 39) – Routin Acu.: same routine acupunture as in intervention grp was applied; same as IG Drop outs: A=0 | Outcome instruments: Pain: NR Disability: NR Results: Baseline: NA Pain: NR Disability: NR Immediate post tx: NA Pain: NR Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Other:cure rate, effective rate Results: Immediate post tx: Cure rate: 29 vs. 16% effective: 8 vs. 12% ineffective: 2 vs. 11% total efficacy: 94.9% vs. 71.8% Short term: NR Intermediate: NR Long term: NR Harms: NR

Table 1.2 Low Back Pain - Acupuncture – Acute/Sub-acute - Non –Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Araki, S (2001)5 Country: Japan Quality score: 10/13 Initial of reviewer: SG | Trial Design RCT Tx duration: single tx Final assessments: immediately post tx N screened: 40 N randomized: 40 N completed tx: 40 N attended last fu: 33 Inclusion: Pts with acute low-back pain (who have gait disturbance; information from author.) Exclusion: no information (more than 3 ds duration of LBP, sciatica; information from author.) | Mean age (SD/range): IG = 44.25 (15) vs. CG = 43.3 (13.8) yrs % of male: 70% total Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Acute, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 20)– Acu: needle(s) inserted into SI3 bilaterally with deqi sensation at supine position and then pts were made to perform back EX, needles left in situ during EX, insertion depth was 2.5 cm, acu needles(50 mm length, 0.20 mm diameter); single tx Drop outs: 7 total in both grps CG (n = 20) – Sham: needling performed to SI3 bilaterally point at supine position, mimicked needle insertion: tapped head of guide tube then pts made to perform back EX, needling gesturing performed during back EX; single tx | Outcome instruments: Pain: VAS (mm)of pain and LBP score (JOA) Disability: JOA Score Results: Baseline: Pain: IG = 66.6 (4.7), CG = 71.5 (4.84) Disability: IG = 4.45 (0.57), CG = 5.35 (0.6) Immediate post tx: Pain: IG = 49.55 (5.06), CG = 55.65 (6.13) Disability: IG = 6.6 (0.72), CG = 6.5 (0.69) Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Other: NA Results: Baseline: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR
Cao, W (2001)6 Country: China Quality score: 0/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: 6hrs – 9 ds Final assessments: immediately post tx N screened: 400 N randomized: 400 N completed tx: NR N attended last fu: NR Inclusion: pts with acute lumbago (severe and very severe pain) who sought medical advice from Dep. of Acu and Moxi and the surgical Dep. Of orthopedics - 338 were outPts and 62 inPts, 106 pts were seen for the first time Exclusion: NR | Mean age (SD/range): 18-72 yrs % of male: 33.8% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: 24.5% acute sprain in the waist; 21.5%; hyperosteogency and osteoporosis of LV, 14.8% acute prolapse of the LVD, 10.3% musculus piriformis, and other causes Duration of Pain: Acute, NR Severity of pain (Grading): grade I vs. grade II - IG1= 7 vs. 28; IG2 = 67 vs.33; IG3 = 73 vs. 27; CG = 69 vs. 31 | Groups IG1 (n = 100)– Acu with filiform needle: 1 - point through point method with twisting manipulation;; 5-10tx, 1tx/2ds Drop outs: NR IG2 (n = 100) – As IG1 + cupping: acu as IG1, cupping used after needling on the sore points Retained for 5-15 minutes; same as IG1 Drop outs: NR IG3 (n = 100) – Same as IG2 + pricking collateral same as IG1 Drop outs: NR CG (n = 100) – As IG3 + moxibusion: As IG3 + moxibustion on affected part using 5 moxa cones until local skin turned from purple; same as IG1 Drop outs: NR | Outcomes: Pain: NA Disability: NA Results: Baseline: NA Pain: Immediate post tx: NA Pain: Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: Curative Effect at 5: IG1(n =7), IG2 (n = 8), IG3 (n = 15), CG (n = 32) improved; CE at 10: IG1 (n = 10), IG2 (n = 11), IG3 (n = 38), CG (n = 33) improved Results: Baseline:NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR
Eisenberg, DM (2007)7 Country: US Quality score: 8/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 5 wks Final assessments: immediately post tx N screened: NR N randomized: 434 N completed tx: 418 N attended last fu: NR Inclusion: Pts with acute LBP for 21 d or less aged > 18 yrs Exclusion: Pain not in LB; pain lasting > 21 d; back of neck surgery in past 5 yrs; history of vertebral fracture or dislocation; unexplained fever or weight loss; (fibromyalgia, drug abuse, arthritis), history of cancer other than non-melanoma skin cancer, osteoporosis, clotting disorders, use of anticoagulant drugs, systemic corticosteroids, pregnancy | Mean age (SD/range): IG1 – IG3 = 43.2 (12.7) vs. CG = 42.7 (12.7) yrs % of male: IG1 – IG3 = 45 vs. CG = 50 Racial composition: 63.9% White Work status: IG1-IG3= 86.5%; CG =82.4%, NS Other socio-demographics: 65.45% Married or with partner Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N- S Duration of Pain: Acute, NR Severity of pain (Grading): NR Co-interventions: Same as interventions | Groups IG (n = 58)– Acu: NR; 10 sessions over 5 wks Drop outs: 4 IG2 (n = 76) – Chiro: NR same as IG1 Drop outs: 4 IG3 (n = 152) - Massage: NR; same as IG1 Drop outs: 4 CG (n = 148) – Usual care: NSAIDs, muscle relaxants, limited bed rest, education, activity alterations; 5 wks Drop outs: 2 | Outcome instruments: Pain: NA Disability: NA Results: Baseline: NA Pain: Disability: Immediate post tx: NA Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR Efficacy data reported for the combination of CAM txs and is not used in this report. | Outcome instruments: QoL/ well being: NR Short term: NR Intermediate: NR Long term: NR Harms: Harms (B): Minor discomfort/soreness; IG1 = 5%, IG2 = 8%, IG3 = 7%, CG = NR
Kenndy, (2008)8 Country: Irelnad Quality score:8/13 | Trial Design RCT- Tx duration: Final assessments: 3 mos after last intervention N screened: 55 N randomized: 48 N completed tx: 45 N attended last fu: 40 Inclusion: 18-70 yrs adults with N-S LBP, with/out referred pain, up to 12 wks duration. Exclusion: red flags (defined by CSAG*), contra-indications to acu; previous acu tx; conflilcting or ongoing tx | Mean age (SD/range): % of male: 54.2 vs. 417% Racial composition: Work status: employed= 54.2% vs. 45.8% sick leave= 29.2% vs. 20.8% Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Acute Severity of pain (Grading): NR Co-interventions: 1- strd advice to remain active (to all pts: back book, evidence-based booklet) 2- uncontrolled Med (prescribed or over the counter -mg and n/d) 3- analgesic use in n=44 (92%) grp 1+ grp2 at baseline | Groups IG (n = 24) – Acupuncture: unilateral or bilateral points with 8-13 needles stimulated manually every 5 min until 30 sec of “de qi” sensation reached; needle retention time = 30 min. The Park Sham Device (AcuPrime, UK) with verum acu single use needles with guide tube, size 0.25 mm × 40 mm; at least 3, max 12 tx in a 4-6 wk Drop outs: 3 CG (n = 24) – Placebo: same device as intervention grp; non-penetrating sham needles (size 0.3 mm × 40 mm, AcuPrime Dong Bang) in same acu points and clinical protocol; schedule as IG Drop outs: 8 | Outcomes: Pain: VAS (average and worst, 0 - 100) Disability: RMDQ Results: Immediate post tx: Pain, average: 27.3 vs. 36.3 RMDQ: 6.0 vs. 12.8 Short term (3 mos post tx): Pain, average: 26.5 vs. 40.7 RMDQ: 50. vs. 7.0 Intermediate: Long term: NR | Outcomes: QoL/ well being: NR Other: work absenteeism; Med used, exit questionnarie Results: Immediate post tx: tablet use: 1.0 (0.3) vs. 4.2 (0.6) Days off work: 13.9 vs. 10.9 ds Short term: NR Intermediate: NR Long term: NA Harms: NR
Kittang, G (2001)9 Country: Norway Quality score: 7/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: 10 ds/2 wks Final assessments: 6 mos N screened: NR N randomized: 60 N completed tx: 57 N attended last fu: 57 Inclusion: 18-67 yrs with acute LBP (lasting less than 10 ds) Exclusion: Neurologic outcomes, rheumatic illness, malign disease, systemic use of anti-inflammatory drugs or steroids before inclusion and use of medicine that may interact with anti- inflammatory drugs | Mean age (SD/range): NR % of male: NR Racial composition: NR Work status: 2 of 3 on sick leave at time of inclusion Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Acute, NR Severity of pain (Grading): NR Co-interventions:Advice and EX | Groups IG (n = 30) – Acupuncture: needling in “lumbago 1 and 3” with medical lumbago and in “upper lip” with more lateral pain. Later txs were 5 needles across at level L2, at Ashi points (local pain point) and in both ankles. Analgesia was allowed and sick leave provided when necessary; 4 tx, within 2 wks Drop outs: 3 (not clear which grp or at what time point) CG (n = 30) – Medication: Naproxen 500 mg twice daily for 10 ds Drop outs: NR | Outcomes: Pain: VAS Results: Baseline: Pain: NR Immediate post tx: Pain: IG = 13 (0), CG = 12.9 (0) Short term: IG = 6.4 (0), CG = 8.7 (0) Intermediate: IG = 9.6 (0), CG = 14.4 (0) Long term: NR | Outcomes: QoL/ well being: NR Other: use of analgesic drugs: IG used significantly less drughs during the 1^st^ wk after start of tx than those receiving naproxen: 2/28 vs. 11/29, P < 0.01 Harms: gastroenteric side effects (0/28 vs. 15/29, p < 0.01)

Table 1.3 Low Back Pain- Acupuncture – Chronic Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Ceccherelli, F (2001)10 Country: Italy Quality score: 9/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 6 wks Final assessments: 3 mo N screened: NR N randomized: 42 N completed tx: 42 N attended last fu: 42 Inclusion: Lumbar myofascial pain, continuous pain > 3 mo or recurrent acute pain >1 mo, not been resolved with drug therapy Exclusion: Paraplegia or quadriplegia, radiographic evidence of osteoporosis or neurological signs; systemaic organic diseases, psychiatric inllnes | Mean age (SD/range): IG = 41.65 (11.37) vs. CG = 41.63 (8.87) yrs % of male: full sample: 71% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | LBP Cause of Pain: N-S (lumbosacral myofacial pain) Duration of Pain: chronic (lumbosacral myofacial pain), NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 21)– Deep-Acu: Sedatelec 300um, 10, 29 and 49mm lengths. Points were extra 19, VG6, bilaterally: GB34, UB54, UB62 + 4 TP or most painful points in lumbar area. Needles stimulated for 1 min after insertion and for 20s/5, 10, 15min, Freq was 2 Hz; 20min/session, 8 sessions total in 6 wks Drop outs: none CG (n = 21) – Superficial Acu: same as described for acupunture, but the depth of insertion was only 2mm in the skin; same as IG Drop outs: none | Outcome instruments: Pain: McGill Pain Questionnaire: No. of words; total scores (B, C) Results: Baseline: Pain: IG = 13.81 (3.95), CG = 13.7 (3.49); IG = 35.4 (14.53), CG = 34.75 (11.43) Immediate post tx: Pain: IG = 7.81 (4.88), CG = 10.4 (6.76); IG = 14.54 (10.88), CG = 22.25 (16.08) Short term: IG = 3.63 (6.13), CG = 8.5 (7.12); IG = 7.5 (12.94), CG = 18 (17.16) Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NA Results: Baseline: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR
Gunn, CC (1980)11 Country: Canada Quality score: 4/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 5-10 wks Final assessments: immediately post tx N screened: 146 N randomized: 55 N completed tx: NR N attended last fu: NR Inclusion: male workers disabled from injury for at least 12 wks; with 8 wks run in period of standard Clinical regimen before admission into the trial; disability periods(12 to 168 wks) wks Exclusion: psychosomatic backache; pts with spontaneous recovery | Mean age (SD/range): Total: 40.6 (range 20-62) yrs % of male: 100% total Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: pts with prior surgery were included Prior CAM intervention: NR Prior surgery related to current complaint: NR | LBP Cause of Pain: Fracture Duration of Pain: Chronic, disability period: 28.6 (12-168) wks Severity of pain (Grading): NR Co-interventions: Standard Tx | Groups IG (n = 28)– Acu+ standard care: dry needling of muscle motor points using traditional acu methods; Needles: 3, 4, and 5 cm L; diameter of 30 gauge; inserted perpendicularly to the skin of muscle zone of innervations; mechanical stimulation by pecking and twirling movements- e stimulation with low voltagle of 9 V for a few sec to each pint or a phasic current applied for 15 min until visible muscle fibrillation until Teh Ch'i phenomenon (soreness, heaviness or pressure, numbness, fullness or distention); once or twice/wk for 10 tx Drop outs: NR CG (n = 27) – STD Tx: NR; NR Drop outs: NR | Outcome instruments: Pain: NA Disability: NA Results: Baseline: Pain: NA Disability: NA Immediate post tx: Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Pain + work status questionnarie n (%) with full recovery; partial recovery; slight recovery; no recovery Other: Results: Baseline: Immediate post tx: IG = 4 (13.8), CG = 0; IG = 14 (48.3), CG = 4 (14.8); IG = 10 (34.5), CG = 11 (40.7); IG = 1 (3.4); CG = 11 (40.7) Short term: Intermediate: NR Long term: NR Harms: NR
Hollisaz, MT (2008) 12 Country: Iran Quality score: 2/13 | Trial Design-RCT Tx duration: NR Final assessments: immediately post tx (last fu is immediately post tx) N screened: NR N randomized: 119 N completed tx: assume 119 N attended last fu: assume 119 Inclusion: Pts with LBP of sciatica origin (> 6 mo) aged ≥ 20 yrs Exclusion: Indication for surgery, reluctance/compliance for attendance < 5 Tx sessions, > 50 yrs old, contraindications of acu Tx (systemic disease, prosthesis, cutaneous infections) | Mean age (SD/range): NR % of male: 45.4 Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: Buttock pain: 80.5% vs. 79% vs. 70%; Paravertebral muscle spasm: 61 vs. 71% vs. 45.5%; Scoliosis: 22 vs. 42% vs. 12; Claudication: 14 vs. 23.7% vs. 12.6% Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Duration of Pain: chronic Severity of pain (Grading): NR Pts were classified into 4 pain intensity groups (VAS 0 – 100) mild = 0-25; moderate 25-50; severe=50-75, dn very severe = 75-100 Co-interventions: NR | Groups IG (n = 41) – Acupncture: 10-15 needles inserted in painful points to depth of 1-5cm. Each session lasted 20 min and a current with 2-10 mA intensity and 4 HZ frequency; 15 sessions in total Drop outs: NR IG2 (n = 38) – Physiottherapy: hot packs, ultrasound, short-wave diathermy, TENS, muscle strengthening; 30 minutes per session; 15 sessions in total Drop outs: NR CG (n = 40) – Placebo needles set on the intended points by adhesives and after turning the machine on the current intensity was zero; every other d over 1 mo: Drop outs: NR | Outcome instruments: Pain: VAS Pain reduction % (intensitiy of last session/ that of beginning) Disability: NR Results: Immediate post tx: % of pain reduction: 62.1% vs. 52.5% vs. 17.5% Short term: NR Intermediate: NR Long term: NR | Outcome instruments: Complication reduction Results: Immediate post tx: Complication reduction: 89.3% vs. 51.8% vs. 31.9% Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: Pain reduction in sever grp was 50.5 vs. 51.6 vs. 37.1 vs. 29% in very severe, sever, moderate, and mild group respectively; % of resolved compications did not differ significantly in 4 pain groups
Itoh, K (2004)13 Country: Japan Quality score: 7/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 6 wks Final assessments: immediately post tx N screened: NR N randomized: 35 N completed tx: 27 N attended last fu: NR Inclusion: Lumbar LBP of at least 6 mo, normal neurologic function of lumbosacral nerves, no pain radiation, persisting pain intensity VAS => 5 (0=no pain, 10=worst pain imaginable) despite after taking therapy with lornoxicam and tramadol Exclusion: Major trauma or systemic disease, other ongoing txs | Mean age: G1 = 70.1 – 73.8 yrs % of male: 28.6% Racial composition: NR Work status: NR Other socio-demographics:NR Co morbidities: Spondylosis (n=8) Osteoporosis IG1, CG (n=2), IG2 (n = 3) Compression fracture IG1, CG (n=1), IG2 (n = 2) Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | LB Cause of Pain: NR Duration of Pain: Chronic, IG1 = 5.2 (2.6), IG2 = 7.4 (4.35), CG = 5.4 (3.7) yrs Severity of pain (Grading): NR Co-interventions:Po ultice:IG1 (n=7), IG2(n = 6), CG (n =5) Analgesic IG1, IG2(n=3), CG (n = 2) Vit. D IG1 (n=1), IG2 (n = 3), CG (n = 2) | Groups IG1 (n =12 ) – Superficial-Acu: needles 0.2mm x 50 mm inserted in the skin over the TP to 3 mm depth, when pt felt dull pain, manipulation stppd but retained for 10 min; 3 wks x 2tx periods, 2 wks between tx periods Drop outs: A = 3 IG2 (n = 10) – Deep-acu: Same as IG1 but 20 mm in depth, stransverse oscillatory rotped when twitch was elicited and retained for 10 min; same as IG1 Drop outs: A = 1 CG (n = 13) – Standard-acu: in lumbar and lower extremity (depth of 20mm) and the “sparrow pecking” technique needle was retained for 10 more min; same as IG1 Drop outs: A = 3 | Outcome instruments: Pain: VAS (B) Disability: RMDQ)immediate post tx Results: Immediate post tx: Pain: (n = 9): IG1 = 48.2 (30.5), IG2 = 33.1 (19.2), CG = 53.7 (21.9) (P>0.05) Disability: (n= 9): IG1 = 4.3 (2.2), IG2 = 4.2 (1.2), CG = 4.2 (4.3) (P>0.05) Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Results: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR
Nan, L (2005)14 Country: China Quality score: 3/13 Initial of reviewer: SG | Trial Design RCT Tx duration: not clear Final assessments: immediately post tx N screened: 366 N randomized: 360 N completed tx: 360 N attended last fu: NR Inclusion: pts age 18 - 65 yrs with lumbar strain hyperplastic spondylitis in reference with relevant stand. implementation in Traumatology in Chinese Medicine Exclusion: not in conformity of the dx/ or associated with other syndromes or complications; poor compliance; other severe primary diseases | Mean age (SD/range): IG = 45.8 (11.2) vs. CG = 46.2 (10.9) yrs % of male: NR Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Group 1a & 2a – Lumbar strain; 1b & 2b – hyperplastic spondylitis Duration of Pain: Chronic, IG = 3.14 (0.98), CG = 3.11 (0.90) yrs Severity of pain (Grading): NR Co-interventions: NR | Groups IG 1a (n = 88), 1b(n = 92– 1a – Dermal needling: gentle tapping method in local pain/or along the meridian till the local skin turned red; heavy tapping for obvious pain till slightly bleeding; 5 tx/course, 2 courses, 10 tx sessions total; 1b – Dermal needling: same as above; 5 tx course, x 2 courses, 10 sessions total Drop outs: 3 CG 2a (n = 91), 2b (n = 89) – 2a - Body Acu: accord. differentiation of syndromes in Chinese medicine; Needles: 0.34 gauge, and 30 - 70 mm L, 15 - 60 mm deep perpendicular or oblique needling till soreness and distension appeared- points: (BL 25), (BL 23); 2b – Same as above; 7 tx, once/ 2ds/ course, 14 txs Drop outs: 3 | Outcome instruments: Pain: Pts with grade II pain(easily neglected) Results: Baseline: Pain: NA Immediate post tx: Pain: IG 1a = 29, 1b (34); CG 2a = 32, 2b = 29 Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Other: Pts with no pain(B) Results: Baseline: Immediate post tx: IG 1a = 37, 1b = 24; CG 2a = 27, 2b = 22 Short term: NR Intermediate: NR Long term: NR Harms: NR
Wang, BX (2004)15 Country: Pakistan Quality score: 2/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 5-7 ds Final assessments: immediately post tx N screened: NR N randomized: 40 N completed tx: 37 N attended last fu: NR Eligibility criteria:; - inclusion: Pts with intervertebral disc protrusion aged => 18 yrs suffering from radiating pain to the lower limb for > 2 yrs; - exclusion: NR | Mean age (SD/range): Mean: 46 yrs Range: 20-59 % of male: 75% Racial composition: Pakistani Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Mechanical conditions but not cancer % NS: 100% of all pts % S: Duration of Pain: Chronic, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 23)– E-Acu: Needles inserted in acupoints huantiao and weizhong and twirled until pts felt soreness, heaviness, and distention; G6805-II type electric stimulator was used for 25 min.; 1tx/d for 7d Drop outs: 3 (NR) CG (n = 17) – Medication: Diclofenic - 25 mg/tablet; Given post cibum at 50 mg tid for 5 ds Drop outs: NR | Outcome instruments: Pain: Pain intensity (tenderness) at buttock (B) Disability: NA Results: Baseline: Pain: IG = 49.5 (1.4), CG = 50.3 (1.2) Disability: NA Immediate post tx: Pain: IG = 25.7 (2.3), CG = 33.3 (2.5) (P<0.05) Disability: Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NA Results: Baseline: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR Summary of results (if provided): Greater decrease in pain intensity in the buttock for pts treated with E-Acu compared to those treated with the Med

Table 1.4 Low Back Pain - Acupuncture - Chronic - Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Brinkhaus (2006)16,17 Country: Germany Quality score: 8/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 8 wks Final assessments: N screened: 301 N randomized: 297 N completed tx: 397 N attended last fu: NR Inclusion: clinical diagnosis of CLBP, aged 40 - 75 yrs, pain intensity of at least 40, on a 100 mm VAS on last 7 ds, only use of steroid anti-inflammatory drugs for pain in last 4 wks Exclusion: protrusion or prolapse of 1 or more intervertebral discs with concurrent neurological symptoms, radicular pain, prior vertebral column surgery; other S causes of pain | Mean age (SD/range): IG1 = 59.1 (8.8), IG2 = 58.2 (9.4), CG = 58.9 (9.5) yrs % of male: IG1 = 36.6%, IG2 = 24.7%, CG = 31.6% Racial composition: NR Work status: NR Other socio-demographics:NR Co morbidities:NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Chronic, IG1 = 14.7 (11), IG2 = 13.6 (10.5), CG = 15.8 (11.8) yrs Severity of pain (Grading): NR Co-interventions:an algestic med. use in last 6 mos(n,%): IG1 = 59 (40.4), IG2 = 27 (37), CG = 26 (32.9) | Groups IG (n = 145)– Acu: 4 local points: bladder 20-34; bladder 50-54; gallbladder 30; governing vessel 3, 4, 5, and 6; extraordinary points Huatojiaji and Shiqizhuixia. needled at least 2 distant points from (bilaterally): small intestine 3; bladder 40, 60, and 62; kidney 3, and 7; gallbladder 31, 34, and 41; liver 3; and governing vessel 14 and 20- in addition other acu;12 sessions, 30 min/session over 8 wks Drop outs: C = 7, D = 1, E = 2 IG2 (n = 71) –Sham-Acu: NR; NR Drop outs: C = 5, E = 2 CG (n = 79) – Waiting list: no tx; NR Drop outs: C= 5 | Outcome Instrumets: Pain: VAS-ITT analysis Disability: FFbH-R score; PDI score Results: Baseline: Pain: IG1 = 63.2 (13.2), IG2 = 66.6 (15.7), CG = 66.1 (13.6) Disability: IG1 = 57.1 (18.6), IG2 = 57.2 (17.3), CG = 56.7 (20); IG1 = 28.9 (11.1), IG2 = 31.5 (11.1), CG = 31 (13.3) Immediate post tx: Pain: IG1 = 34.5 (28.5), IG2 = 29.8 (23.6), CG = 25.1 (6.9) Disability: IG1 = 66.8 (18.3), IG2 = 62.9 (20.3), CG = 57.7 (19.9); IG1 = 18.8 (13.1), IG2 = 21.5 (13.2), CG = 27.1 (14.1) | Outcome instruments: QoL/ well being: SF-36 (physical health) Other: Results: Baseline: IG1 = 32.8 (8.2), IG2 = 31.8 (8.3), CG = 31.6 (8.2) Immediate post tx: IG1 = 40.5 (9.7), IG2 = 36.2 (10.3), CG = 33.9 (9.5) IG1 vs. CG =p<0.001, IG1 vs. IG2 = p=0.16 Short term: NR Intermediate: NR Long term: NR Harms: NR
Carlsson, CPO (2001)18 Country: Sweden Quality score: 6/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 8 wks Final assessments: 6 mos N screened: NR N randomized: 50 N completed tx: N-S N attended last fu: NR Inclusion: lumbar or lumbosacral LBP for at least 6 mos; no radiation of pain below the knee level; normal neurologic examination findings of lumbosacral nerve function Exclusion: major trauma or systemic disease; pregnancy; hx of acu tx | Mean age (SD/range): total = 49.5 (15.4) yrs % of male: 34% total Racial composition: NR Work status: total: retired 17 (34%), full time 12 (24%), unemployed 1 (2%) Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: total 2 (4%) | Cause of Pain: N-S Duration of Pain: total= 9.5 (7.0)yrs Severity of pain (Grading): NR Co-interventions: c orsets, nerve blocks, analgestics, TENS, and internse PT includingtraction , warmth, and EX | Groups IG1 (n = 18)– Manual acu: local points, BL24, BL25, BL26, Ex Jiaji and distal points, LI11, LI4, BL40, BL57 and BL60; “de qi” feeling sought at needle-tip depth of 2-3 cm, needles (0.3 and 0.32 mm and length 30 and 70 mm) stimulated 3 times during 20 min tx sessions to restore de qi feeling; once/wk for 8 wk Drop outs: 13 IG2 (n = 16) – EA: 4 needles, 1 pair/side in LB, freq 2Hz every 2.5s, interrupted by a 15 Hz train for 2.5s using Chinese acu ES; 2-3 sessions/as IG1 Drop outs: -- CG (n = 16) – TENS: mock TENS given by impressive, stationary, disconnected GRASS, electrodes placed on most painful area in LB; same as IG1 Drop outs: 10 | Outcome instruments: Pain: VAS (A, B)in the morning; in the evening Results: Baseline: Pain: IG1 + IG2 = 57 (21), CG = 47 (23) Immediate post tx: Pain: NR Short term: % change from baseline in the morning: 1^st^ = 88%, 2^nd^ = 76% % change from baseline in the evening 1^st^ = 87%, 2^nd^ = 74% Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NA Other: Results: Baseline: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR Summary:
Cecherelli, F (2003)19 Country: Italy, Padova Quality score: 7/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 5-10 wks Final assessments: immediately post tx N screened: 31 N randomized: 31 N completed tx: 31 N attended last fu: NR Inclusion: Pts with chronic “lombalgia” meaning LBP (pain > 3 mos) Exclusion: radicular signs associated with scoliosis as demonstrated on X-ray or degenerative disc disease with significant reduction of interdiscal spaces, radicular symptoms with dural sac signs, Pts showing signs of neuro-muscular disease | Mean age (SD/range):IG = 57.17 (±13.06), CG = 49.36 (±11.98) yrs % of male: IG= 31 %, CG = 27% Racial composition: Europian-Italian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: NR Duration of Pain: Chronic > 3 mos Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 16)– Acu: the needles were inserted in the muscles and in the intraspinal ligaments. The following points were stimulated manually for 20 seconds per tx: Ex 29 (Shiqizhuixia) 3 GV (yaoyangguan) 30 BL (Baihuanshu)) 31 BL (Shanglio) 60 BL (Kunlun) 62 BL (Shenmai); 1 session/wk for 5 wks Drop outs: None CG (n = 15) – Acu: same as IG; 10 tx of acu, 1 tx/wk for 10 wks Drop outs: None | Outcome instruments: Pain: NA Results: Baseline: Pain: NA Immediate post tx: Pain: Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NA Results: Baseline: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: IG = 11 pts obtained a good result (68.8%), 1 an unsatisfactory result, and 4 a poor result (25%). The remaining pain was 65.5% of the original pain. CG= 13 pts (86.7) had a good result) and 2 a poor result (13.3%). The remaining pain was 43.9% of the original pain
Cherkin, DC (2001)20 | See LBP massage section | See LBP massage section | See LBP massage section | See LBP massage section | See LBP massage section | See LBP massage section
Cherkin, DC (2009)21 Country: US Quality score: 6/13 Initial of reviewer: SG | Trial Design – RCT Tx duration: 7 wks Final assessments: 3 mos N screened: 2605 N randomized: 638 N completed tx: 638 N attended last fu: 606 Inclusion: Pts aged 18-70 yrs receiving care for CLBP (3-12 mo) within the past yr Exclusion: Specific causes of BP (cancer, fractures, spinal stenosis, infection), back problem complication (back surgery, sciatica), contraindication to acu | Mean age (SD/range): 46 – 49 yrs % of male: IG1 = 32, IG2 = 54, IG3 = 40, CG = 36% Racial composition: White/Hispanic Work status: employed IG1 = 22, IG2 = 20, IG3 = 22, CG = 19 Other socio-demographics: Married: 58.3% Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: N-S, 21.5% with radiating pain Duration of Pain: Chronic, NR Severity of pain (Grading): NR Co-interventions: Electro-stimulation, moxibustion, herbs were also prescribed | Groups IG1 (n = 157)– Ind-Acu: 32-gauge needles were used (0.25 mm) at least 1.5" in length; needling depth varied from 1 to 3 cm, 10.8 (5-20) needles retained for 18 (15-20) min, twice for 3 wks, then once/wk for 4 wks Drop outs: C=10,D = 16 IG2 (n = 158) – St-Acu: same as IG1 with 8 commonly used acu points Du 3, Bladder 23-bilateral, LB ashi point, Bladder 40-bilateral, Kidney 3-bilateral, needled for 20 min; same as IG1 Drop outs:C=6, D=11 IG3 (n = 162) – Sham: toothpick in a needle guide tube, twirling for 10 min; same as IG1 Drop outs: C=3, D=10 CG (n = 161) – Usual care: self-care book; NA Drop outs: C=13, D=18 | Outcome instruments: Disability: RMDQ short- and intermediate-term post-tx Results: Baseline: Disability: IG1 = 10.8 (5.2), IG2 = 10.8 (5.6), IG3 = 9.8 (5.2), CG = 11 (5.2) Immediate post tx: Disability: NR Short term: IG1 = 6.4 (5.3), IG2 = 6.3 (5.7), IG3 = 5.4 (4.9), CG = 8.9 (6) Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Results: Immediate post tx:NR Short term: NR Intermediate: NR Long term: NR Harms: 11 pts had moderate short-term and 1 pt had severe AE; IG1 = 6, IG2 = 6, P = 0.04
Chu, J (2004)22 Country: US Quality score: 7/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: 3 wks Final assessments: 2 wks N screened: NR N randomized: 36 N completed tx: NR N attended last fu: NR Inclusion: Pts with CLBP (duration ≥ 3 mo) Exclusion: Radiation of pain below the buttock, drug/alcohol abuse, sciatica, spinal surgery, spinal nerve root or spinal cord injury, previou use of Acu, skin infections, open wounds, bleeding disorders, immune deficiencly, valvular heart disease, pace makers, pregnancy | Mean age (SD/range): 53.4 (13.9) yrs % of male: 50% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Herniated nucleus pulposus (n=4) Lumbar spondylosis (n=4) Spondylolisthesis (n=2) Duration of Pain: Chronic, 28.2 (19.1) yrs Severity of pain (Grading): NR Co-interventions: NR | Groups IG1 (n =12 ) – E-MS(ETOIMS): Monopolar 37 mm-long EMG needle electrode inserted into paraspinal muscle sites (T10 - S1), kept for 2 secs stationary then withdrawn, electric current (frqcy: 2 HZ and intensity: 2 mA) was supplied at individual points; 20 min/session Drop outs: NR IG2 (n = 12) – MS: same as IG1 minus electric current; same as IG1 Drop outs: NR CG (n = 12)–SS: Skin stimulation, insertion of EMG needle electrode limited to skin (no penetration, no electricity) Drop outs: NR | Outcomes: Pain: Pain intensity (VAS): B (right after, 1 wk post-Tx, and 2 wks post-Tx) Disability: NA Results: Baseline: Pain: IG1 = 4.3 (2.3), IG2 = 4.6 (2.1), CG = 4.2 (1.9) Immediate post tx: Pain: IG1 = 2.3 (1.1), IG2 = 3.9 (1.8), CG = 3.5 (2.3) (P < 0.01) Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NA Results: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR
Coan, R (1980)23 Country: USA Quality score: 3/13 Initial of reviewer: SG | Trial Design RCT Tx duration: NR Final assessments: 3-6 mos N screened: NR N randomized: 39 N completed tx: NR N attended last fu: NR Inclusion: LBP for 6 mos or more, no previous acu tx, no history of diabetes, infection or cancer, not more than 2 back surgeries Exclusion: NR | Mean age (SD/range): IG = 47.2, CG = 47 yrs % of male: IG = 43.5%, CG = 50% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: NR Duration of Pain: Chronic, IG = 8.2, CG = 12.6(assuming yrs)-SG Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 23)– Acu (immediate): performed according to the classical Oriental meridian theory of promoting healing by stiumlating the energy flow in the body. In some pts, E-Acu was used; NR Drop outs: NR CG (n = 16) – Acu (delayed): same as IG; NR Drop outs: NR | Outcome instruments: Pain: VAS 10cm for pain (0-10) (A, C, D) Results: Baseline: Pain: IG = 5.5, CG(A1) = 4.8, CG (A2)= 4.7 Immediate post tx: Pain: NR Short term: IG = 2.7 (2.8), CG (A1) = 2.8 (2), CG (A2) = 2.8 (1.9) Intermediate: IG = 3.8 (1.7), CG (A1) = 3.4 (1.4), CG (A2) = 4.6 (-0.1) Long term: NR | Outcome instruments: QoL/ well being: NR Results: Baseline: NA Immediate post tx: NR Short term: NR Intermediate: NR Long term: NR Harms: NR
Fu ZH 2006^24^ Country: China Quality score: 3/13 Initial of reviewer: SG | Trial Design RCT Tx duration: NR Final assessments: immediately post tx N screened: NR N randomized: 60 N completed tx: 60 N attended last fu: NR Inclusion: Adults (20-60 yrs) with CLBP between the 12th rib and gluteal fold Exclusion: systemic disorders, disc/spine surgery, psychiatric diseases, taking analgesics, hormones | Mean age (SD/range): IG = 53.3 (12.4) vs. CG = 58.8 (10.8) yrs % of male: IG = 0.437%, CG = 0.5% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: N=-S Duration of Pain: Chronic, IG = 5.43 (7.45); CG = 5.56 (6.54) Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 32)– Fu’s subcutaneous needling: needle penetrates subcutaneously into layer in insertion points chosen based on experience and ancient Chinese medical book; insertion points were chosen at the same side with suffered back; if both sides afflicted, one more severe side was treated; NR Drop outs: NR CG (n = 28) – minimal needling: NR; NR Drop outs: NR | Outcome instruments: Pain: MRP -VAS (B); PUP - VAS (B) Disability: Results: Baseline: Pain: IG = 5.22 (2.47), CG = 4.32 (2.13); IG = 5.28 (2.22), CG = 4.07 (2.19) Disability: Immediate post tx: Pain: IG = 2.56 (2.59), CG = 3.79 (2.33); IG = 2.91 (2.48), CG = 3.71 (2.09) Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR
Giles, LG (2003)25,26 Country: Australia Quality score: 6/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 9 wks Final assessments: 1 yr N screened: 533 N randomized: 115 N completed tx: 69 N attended last fu: 62 Inclusion: pts at least 17 yrs old with uncomplicated mechanical spinal pain for minimum of 13 wks Exclusion: pts with nerve root involvement, spinal anomalies (other than sacralization or lumbarization), pathology other than mild to moderate osteroarthrosis, spondylolisthesis of L5 or S1 exceeding Grade 1 | Mean age (SD/range): IG1 = 23.8 (4.8), IG2 = 25 (8.1), CG = 29.5 (2.07) yrs % of male: IG1 = 55.9, IG2 = 51.4, CG = 57.5 Racial composition: NR Work status: NR Other socio-demographics: skilled trade: 28.8% Co morbidities: Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N- S Duration of Pain: chronic (> 13 wks) Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 36)– Acu(LB, neck, thorax): needling the TP & distal analgesia producing sypatholytic acu points below the elbow or knee, intervals for 20 min- insertion depth 20-50 mm, kin the maximum pain area and up to 5 mm in the distal points; same as IG2 Drop outs: B = 14, E = 6/20 IG2 (n = 36) – Spinal manipulation: high velocity, low amp thrust to a joint; 20 min/session, 2 tx/wk up to 9 wks Drop outs: B = 11, E= 4/23 CG (n = 43) – Medication that has not been tried: Drop outs: B = 21, E= 12/19 | Outcome instruments: Pain: VAS (1 - 100)- ITT Disability: Oswestry Results: Baseline: Pain: IG1 = 6 (2.2), IG2 = 6 (2.9), CG = 5 (3.7) Disability: IG1 = 30 (17.03), IG2 = 22 (22.96), CG = 32 (19.3) Immediate post tx: Pain: IG1 = 4 (3.7), IG2 = 3 (5.2), CG = 5 (3.7) Disability: IG1 = 26 (20.74), IG2 = 14 (24.4), CG = 32 (23.7) Short term: NR Intermediate: IG1 = 13 (22.9), IG2 = 16 (17.8), CG = 24 (25.2) | Outcome instruments: QoL/ well being: NR Results: Immediate post tx:NR Short term: NR Intermediate: NR Long term: NR Harms: N=22, 13 in IG1, 4in IG2, 5 in CG, n=1 committed suicide after end of tx; most frequent AEs were hematoma and bleeding
Grant, DJ (1999)27 Country: U.K Quality score: 6/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 4 wks Final assessments: 3 mos N screened: 81 N randomized: 60 N completed tx: 60 N attended last fu: 60 Inclusion: Pts at least 60 yrs old with complain of back pain of at least 6 mos duration Exclusion: Tx with anticoagulants, tx with systemic corticosteroids, dementia, previous tx with acu or TENS, cardiac pacemaker, other severe concomitant disease, inability of Pt or caregiver to apply TENS machine. | Mean age (SD/range): IG = 75 range (60-83), CG = 72 (60-90) yrs % of male: 6.25%, vs. 14.28% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | LBP Cause of Pain: N-S Duration of Pain: Chronic, NR Severity of pain (Grading): NR Co-interventions: Pts were allowed to continue the analgesic use | Groups IG (n = 32)– Acu: (32 gauge, 1.5 inch length with guide tube). Points were as in routine clinical practice, using only points on the back. 6 needles used on average at each tx with minimum of 2 and a max of 8.; 2 tx of 20min/wk for 4 wks Drop outs: 2 CG (n = 28) – TENS: standard make and model of machine (TPN 200, Physio-Med-Servics) using 50 Hz stimulation iwht the intensity adjusted to suit the Pts. Units were used by Pts or the caregiver at home; 30 min/session, max of 6 hrs/d, fu of 20 min/session, twice/d Drop outs: 1 | Outcome instruments: Pain: VAS- reported as Median (IQR), converted to mean (SD) Disability: NHP-reported as median (IQR) converted to mean (SD) Results: Baseline: Pain: IG = 140(P =66), CG = 101 (P = 43.7) Disability: IG = 76.7 (35.3)(P = 33.2), CG = 50.1 (40) (P = 34.4) Immediate post tx: Pain: NR Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NA Results: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: (n = 2): influenza and immobility following dental tx which required hospitalization; (n = 1): acute depression
Haake, M (2007)28 Country: Germany Quality score: 10/13 Initial of reviewer: SG | Trial Design RCT Tx duration: up to 7 wks Final assessments: immediately post tx N screened: 1802 N randomized: 1162 N completed tx: 1117 N attended last fu: NR Inclusion: > 18 yrs old adults with CLBP for ≥ 24 wks Exclusion: Received acu for LBP at any time in the past, history of spinal fracture, disc or spinal surgery, infections/tumor of the spine, bone/joint disorder, scoliosis, chronic pain, drug abuse, pregnancy or epilepsy | Mean age (SD/range): IG1 = 49.6 (14.6), IG2 = 51.3 (14.5), CG = 49.2 (14.8) yrs % of male: IG1 = 42.6%, IG2 = 42.5%, CG = 36.2% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: N-S Duration of Pain: Chronic, 8 yrs (same for all grps) Severity of pain (Grading): NR Co-interventions: None | Groups IG1 (n = 387)– Acu (verum): Acu included fixed points and individual points according to Chinese medicine; 14-20 needles inserted to a depth of 5-40 mm depending on location. Induction of de Qi in the body was elicited by ME; 2 sessions/ wk, 5 more session if pts experienced 10-50% reduction in pain Drop outs: C = 10 IG2 (n = 388) – Standard therapy: 10 sessions of PT, EX, NSAIDs, pain Med up to max daily dose; same as IG1 Drop outs: C = 24 CG (n = 387) – Sham acu: sham needles were only superficially (1-3 mm) inserted without stimulation; up to 7 wks Drop outs: C = 11 | Outcome instruments: Pain: Pain: CPGS (D) Disability: HFAQ (D) Results: Baseline: Pain: IG1 = 67.7 (13.9), IG2 = 67.8 (14.6), CG = 67.8 (13.2) Disability: IG1 = 46.3 (14.7), IG2 = 46.7 (14.5), CG = 46.3 (15.3) Immediate post tx: Pain: Disability: Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: SF-12 (physical score) Other: Results: Baseline: IG1 = 31.8 (6.8), IG2 = 31.6 (6.8), 31.5 (6.9) Immediate post tx: NA Short term: NR Intermediate: IG1(n = 373) = 41.6 (10.5), IG2 (n = 364) = 35.8 (9.5), CG (n = 372) = 39.5 (10.1) Long term: NR Harms: NR
Hirota, S (2005)29 Country: Japan Quality score: 5/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: 5 wks Final assessments: immediately post tx N screened: 12 N randomized: 9 N completed tx: NR N attended last fu: NR Inclusion: pts with chronic (> 6 mos) LBP Exclusion: NR | Mean age (SD/range): NR, aged 65+ % of male: NR Racial composition: Assuming all Asians Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Not S % NS: all pts Duration of Pain: chronic, Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 4) – Trigger point needling 1tx/wk for 5 wks Drop outs: NR CG (n = 5) – Tender point needling 1 tx/wk for 5 wks Drop outs: NR | Outcomes: Pain: VAS Disabilty: RDQ Disability: RDQ Results: Baseline: Pain: 72.3 (3.1) vs. 71.6 (3.9) Disability: 3.1 (1.4) vs. 5.8 (4.0) Immediate post tx: Pain: 61.5(29.3) vs. 71.5 (24.3) Disability:7.5 (1.9) vs. 9.0 (4.1) Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Other: NA Results: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: After tx period, VAS and RDQ values improved sign. In IG, no sign. improvements in CG
Hollisaz, MT (2008)12 Country: Iran Quality score: 2/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 1 mo Final assessments: immediately post tx N screened: NR N randomized: 119 N completed tx: NR N attended last fu: NR Eligibility criteria:; - inclusion: Pts with LBP of sciatical origin (> 6 mo) aged => 20 yrs; - exclusion: Indication for surgery, reluctance/compliance for attendance < 5 Tx sessions, > 50 yrs old, contraindications of acu Tx (systemic disease, prosthesis, cutaneous infections) | Mean age (SD/range): NR % of male: 45.4% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: Buttock pain: 80.5% Paravertebral muscle spasm: 61.0% Scoliosis: 22.0% Claudication: 14.6% Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: NR Duration of Pain: Chronic, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 41)– E-Acu: 10-15 needles inserted in painful points to depth of 1-5cm.20min/session, current with 2-10 mA intensity and 4 HZ frequency; NR Drop outs: NR IG2 (n = 38) – Physiotherapy: 30min/session, hot packs, ultrasound, short-wave diathermy, TENS, muscle strengthening; NR Drop outs: NR CG (n = 40) – Placebo: instead of needles, pts set on intended points by adhesives, after turning machine on the current intensity was zero; sessions every other d for 1 mo Drop outs: NR | Outcome instruments: Pain: Pain reduction (%) Disability: NA Results: NA Baseline: Pain: Disability: Immediate post tx: Pain reduction, mean % (SD): 62.1 (18.6) vs. 52.5 (17.5) vs. 17.5 (12.7), p < 0.05 Disability: Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NA Other: complication reduction Results: Immediate post tx: 89.3% vs. 51.8% vs. 31.9% Short term: NR Intermediate: NR Long term: NR Harms: NR Summary of results (if provided): E-Acu more effective in resolving symptoms compared to PT or placebo
Inoue, M (2006)30 Country: Japan Quality score: 9/13 Initial of reviewer: SG | Trial Design RCT Tx duration: single tx Final assessments: immediately post tx N screened: NR N randomized: 31 N completed tx: 31 N attended last fu: NR Inclusion: pts consulted for LBP, newly referred and those re-attending, with only LBP in a limited area, which was exacerbated in particular posture Exclusion: pts with leg symptoms, those unable to locate area of pain, pain was not worsened by changes in posture; pts with symptoms or findings on imaging indicating need for Med/surgery/underlying disease | Mean age (SD/range): IG = 68 (6), CG = 70 (8) yrs % of male: IG = 73.3%, CG = 62.5% Racial composition: NR (assume 100% Asians) Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: lumbar vertebral arthritis (dx by MRI or radiological findings) Duration of Pain: Subacute; chronic, IG = 83 (39), CG = 84 (46) mos Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 15)– Acu: needle (L: 40 mm; D: 0.18 mm- by Seirin Co. Shizauoka, Japan) inserted to a depth of 20 mm at the most painful point and stimulated the needle with sparrow pecking method for 20 seconds; 1 tx Drop outs: 0 CG (n = 16) – Sham Acu: therapist taped the end of guide tube on the skin at the most painful point, without a needle and acted as if they were insuring a needle; 1 tx Drop outs: 0 | Outcome instruments: Pain: Pain (VAS-0= no pain; 100= worse pain) at time B while adopting the most painful position Disability: range of lumbar spinal flx-not abstracted Results: Baseline: Pain: IG = 61 (11), CG = 61 (9) Disability: NR Immediate post tx: Pain: IG = 47 (7), CG = 55 (13) Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NA Other: Results: Baseline: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR
Inoue, M (2000)31 Country: Japan Quality score: 10/13 Initial of reviewer: SG | Trial Design - RCT Tx duration: single tx Fu duration: NR N screened: NR N randomized: 27 N completed tx: 27 N attended last fu: NR Inclusion: Pts with chronic lumbago who attended the university acu clinic as outpt, consent to attend trial Exclusion: neurological findings, pain or numbness in lower extremity; malignancy, infection or inflammatory disease; fracture; lumbago due to urological problem, gynecological problem, digestive problem or cardio-vascular problem; dementia; pregnancy | Mean age (SD/range): IG = 59.6 (21.1) vs. CG = 60.1 (20.7) yrs % of male: NR Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Non S Duration of Pain: chronic, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 15) – Acu: two needling points chosen bilaterally from lumbar area(4 points): BL52 and EX-B7, needles inserted and sparrow-picking technique performed for 20 sec, pts treated one time immediately before regular acu tx; single tx Drop outs: 0 CG (n = 12) – Sham acu: two needling points chosen bilaterally from lumbar area (4 in total) same points as IG, mimicked needle insertions: tapped head of needle guide tube, gesture needling performed for 20 sec, pts treated one time immediately before regular acu tx; single tx Drop outs: 0 | Outcomes: Pain: VAS of pain at the most restricted action (10 cm) Results: Baseline: Pain: IG = 6 (1.7), CG = 5.4 (1.8) Immediate post tx: Pain: IG = 3.9 (2.6), CG = 3.6 (2.1) Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: Other: NR Results: Baseline: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR
Itoh, K (2009)32 Country: Japan Quality score: 6/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 5 wks Final assessments: 10 wks N screened: NR N randomized: 32 N completed tx: 25 N attended last fu: 26 Inclusion: outpts older than 60 yrs+; with lumbar or lumbosacral LBP for at least 6 mos; no radiation of LBP; normal neurological findings of lumbosacral nerve Exclusion: if receiving acu > 6 mos; major trauma or systemic disease; receiving conflicting or ongoing co-interventions | Mean age (SD/range): total: range 61-81 yrs % of male: 37.5% total Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: chronic (> 6 mos) Severity of pain (Grading): NR Co-interventions: no intake of other tx including analgesics, anti-inflammatory agents or poultice containing methylsalicylic acid during the study | Groups IG1 (n = 8)– Acu: (BL23), (BL25), (BL32), (BL40), (BL60), (GB30) and (GB34). Stainless steel needles (0.2 mm x 40 mm, Seirin Co Ltd) inserted into the muscle to a depth of 10 mm using 'sparrow pecking' technique for 15 minutes on the affected LBP; 1 tx/wk for 5 wks Drop outs: 1 IG2 (n = 8)– TENS: 15 min on most tender point and near side of point; as IG1 Drop outs: 2 IG3 (n = 8)– Acu + TENS: 15 minutes of TENSE + 15 min of acu as described for grp 1 and 2; as IG1 Drop outs: 3 CG (n = 8) – transverse oscillatory rotical poutice: transverse oscillatory rotical poutice only when necessary; NR Drop outs: 1 | Outcomes: Pain: VAS 10 cm (lower better) Disability: (RDQ)-24 items Results-Baseline: Pain Immediate post tx: IG1 = 37.4 (25.9), IG2 = 53.2 (25.1), IG3 = 36.8 (53.1 (27.9) RMD, mean: IG1 = 5.4, IG2 = 6.2, IG3 = 3.8, CG = 7.3 Short term: IG1 = 43.3 (25.7), IG2 = 58 (23.7), IG3 = 49.2 (10.3), 58.1 (28.9) RMD-mean: IG1 = 6.7, IG2 = 7.5, IG3 = 6.5, CG = 7.7 Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NA Results: Baseline: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: deterioration of symptoms: IG3 = 1 dropout, 12.5%
Itoh, K (2006)33 Country: Japan Quality score: 8/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 3-12 wks Final assessments: immediately post tx N screened: 26 N randomized: 26 N completed tx: 23 N attended last fu: NR Inclusion: pts aged at least 65 yrs with tx of LBP- lumbar or lumbosacral pain for at least 6 mo; leg pain if minor severity in comparison to back pain; normal neurological exam findings of lumbosacral nerve function Exclusion: major trauma or systemic disease; other conflicting or on-going txs; pts with medical conditions were included if there had been no change in drugs or dosage | Mean age (SD/range): IG = 73.5 (10) vs. CG = 78.8 (4.7) yrs % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Spondylosis/Osteoporosis/compression/fracture Duration of Pain: chronic, IG = 4.2 (3.5); CG = 5.4 (6.2) yrs Severity of pain (Grading): NR Co-interventions: baseline meds: anti-inflammatory poulitice Med CG=3/13 | Groups IG (n = 13)– Trigger point Acu: needles (0.2 mm × 50 mm, Seirin, Japan) were inserted into the skin over the TP to a depth of 10-* 40 mm, appropriate to the target muscle. Attempt to elicit a local muscle twitch response using the 'sparrow pecking' technique- needle retained for 10 min post appropriate response; 3 tx/wk, 3-12 wks trial, total 36 tx Drop outs: B = 1 CG (n = 13) – Sham: similar needles as IG used but the tips had been cut off to prevent the needle penetrating the skin. The cut ends were smoothed with sandpaper manually; same as IG Drop outs: B = 2 | Outcome instruments: Pain: Pain: VAS 10 cm scale, A, B Disability: RMQ (RMQ) Results: Baseline: Pain: IG = 65 (13.1); CG = 69 (12.5) Disability: NR Immediate post tx: Pain: IG = 27.3 (13.5); CG (n = 11)= 69.6 (10.9) Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Results: Immediate post tx: NR Short term: NR Intermediate: NR Long term: NR Harms: deterioration of symptoms (n = 1) withdrawal due to AE Summary: RMQ: IG scored significantly lower scores (P < 0.01) than CG - harms of tx are NR (1 WDAE, which was after the 1 st period-data is not extracted)
Kerr, P (2003)34 Country: Northern Ireland Quality score: 4/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 6 wks Final assessments: 6 mo N screened: 60 N randomized: 60 N completed tx: 32 N attended last fu: 34 Inclusion: LBP symptoms > 6 mos (rule out natural recovery processes), with or without leg pain, and with no neurologic deficits Exclusion: contraindications to acu therapy, <18 yrs, pregnancy, underlying systemic disorders and diagnoses of rheumatoid arthritis, osteoarthritis of the spine or cancer. | Mean age (SD/range): IG1 = 42. 6 (11.5 ), IG2 = 42.8 (12), CG = 36.1 (14.9) yrs % of male: IG1 = 50%, IG2 = 35%, CG = 57% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities:NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S (IG1-some with leg pain, detail NR) Duration of Pain: Chronic, IG1 = 86.1 (84.9), IG2 = 72.8 (77.4), CG = 51.6 (44.2) mos Severity of pain (Grading): NR Co-interventions: Pts already on pain Med but details are NR | Groups IG1 (n = 26)– Acu: Bl23, Bl25, GB 30, Bl40, Ki3 and Governor Vessel 4. 11 needles/session, (Seirin acu needles N8, 0.30 × 50mm, c-type needle). The needles were inserted until the sensation of 'ch'i" was produced in prone position. Pts also given leaflet regarding LBP that included standardized advice and EXs; 30min/tx, 1tx/wk for 6 wks Drop outs: 14 IG2 (n = 20)– Placebo- TENS: A nonfunctioning TENS machine was attached to 4 electrodes placed over the lumbar spine; same as IG1 Drop outs: 14 CG (n = 14) – Non-attendees: NR; NR Drop outs: NR | Outcome instruments: Pain: PRI; VAS (mm) Disability: NA Results: Baseline: Pain: IG1 = 29 (11. 1), IG2 = 28.5 (13); IG1 = 79.7 (20.3), IG2 = 76 (17.6) Disability: NA Immediate post tx: Pain: IG1 = 20.3 (9), IG2 = 23.7 (13); IG1 = 51.3 (22.4), IG2 = 61.7 (30.6) Disability: NA Short term: NR Intermediate: N of pts with >50% pain reduction on scale: IG1 = 91%, IG2 = 75% Long term: NR | Outcome instruments: QoL/ well being: SF- 36 (short form 36) Other: Results: Baseline: IG1 = 52.3 (18.7), IG2 = 47.3 (23.7) Immediate post tx: IG1 = 63.9 (20.3), IG2 = 57.5 (23.2) Short term: NR Intermediate: NR Long term: NR Harms: NR
Kwon, Y.D (2007)35 Country: China Quality score: 7/13 Initial of reviewer: SG | Trial Design- RCT Tx duration: 4 wks Final assessments: immediately post tx N screened: 57 N randomized: 50 N completed tx: 47 N attended last fu: 50 Inclusion: lumbar or lumbosacral pain for duration of at least 3 mos; older than 20 yrs of age, LBP as main complaint; normal neurological examination; Exclusion: potential lumbar disease; other diseases such as bleeding, dementia, epilepsy, neurogenic disorder or systemic disease), planned lumbar surgery, prior use of acu within past 6 mo, current use of systematic corticosteroids | Mean age (SD/range): NR (no sign. diff. between grps in age) % of male: IG = 46%, CG = 21% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Non S Duration of Pain: unit NR – mean: IG = 7.38 (6.66), CG = 9.96 (7.14) Severity of pain (Grading): mild: IG = 6 (25%), CG = 5 (21.7%); moderate: IG = 14 (58%), CG = 14 (60.9%); severe: IG = 4 (16.7%), CG = 4 (17.4%) Co-interventions: NR | Groups IG (n = 25) – Acu: ME by reinforcing and reducing by lifting and thrusting needle in 20 min and pts felt de-qi sensation(needles 0.25 mm × 40 mm) inserted into acupoints at depth of 25-30 mm, acupoints: BL 23, BL 52, BL 29, CV2, and GB 30; 3 tx/wk for 4 wks, total of 12 sessions Drop outs: A = 2 CG (n = 25) – Sham acu: ME was not used during the 20 mintues period and subjects did not feel De-qi. Same needles inserted into non acupoints, at depth of 10 - 20 mm away from the acupoints of intervention grp; same as IG Drop outs: A = 1 | Outcome instruments: Pain: VAS scores Disability: RDQ Results: Baseline: Pain: IG = 52.24 (19.76), CG = 51.28 (21.24) Disability: IG = 6.32 (3.86), CG = 6.76 (4.75) Immediate post tx: Pain: IG = 33 (15.75), CG = 35.52 (15.22) Disability: IG = 5.16 (4.86), CG = 4.92 (4.83) Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: PGA, Pt global assessment Results: Baseline: IG = 20.76 (8.97), CG = 21.08 (10.02) Immediate post tx: IG = 16.6 (7.2), CG = 18 (6.7) Short term: NR Intermediate: NR Long term: NR Harms: NR
Lehmann, TR (1983)36 Country: Iowa-University hospital Quality score: 1/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 3 wks Final assessments: 3-6 mos N screened: NR N randomized: 54 N completed tx: 32 N attended last fu: NR Inclusion: Pts with chronic disabling LBP who demonstrate at least minimal levels of motivation and in whom the level of disability would warrant the expense of inPt tx Exclusion: candidates for lumbar surgery; LBP < 3 mos; pregnancy; osteomyelitis of spine, discitis, tumor, ankylosing spondylitis, vertebral fractures and structural scoliosis | Mean age (SD/range): Rprtd for total grp: 39 yrs (range 20-59) % of male: total: 67% Racial composition: NR Work status: total: 94% receiving compensation Other socio-demographics: total: 93% married Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Chronic, total: 48% > 18 mo; 35% between 6-18 mo; 17% between 3-6 mo Severity of pain (Grading): NR Co-interventions: comprehensive multidisciplinary educational program and twice daily EX training sessions. 2 pts were depressed and received tx by a psychiatrist | Groups IG (n = 17)– Acu: stimulus was a biphasic wave at a frequ of 2-4 Hz and increased to the pts level of tolerance. Visible muscle contractions usually occurred. Stimulation loci were along the inner and outer bladder m; 2 tx/wk for 3 wks Drop outs: A = 0, B = 5 D = 0 IG2 (n = 18) –TENSE: stimulated the pts at a pulse width of 250/sec, freq of 60 Hz, and sub threshold intensity- point of stimulation were over the center of pain. pts with leg pain, stimulation was also performed over related nerves.; 1tx/daily for 3 wks Drop outs: B = 4, D = 0 CG (n = 18) – Sham TENSE: same as IG2; same as IG2 Drop outs: B = 3, D = 2 | Outcome instruments: Pain: NA Disability: NA Results: NA Baseline: Pain: Disability: Immediate post tx: Pain: Disability: Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NA Results: Baseline: NA Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR
Leibing, E (2002)37 Country: Germany Quality score: 2/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 24 ds Final assessments: 1 yr + N screened: 208 N randomized: 131 N completed tx: 114 N attended last fu: 131 Inclusion: Non-radiating pain for more than 6 mo. Age 18-65 yrs Exclusion: Abnormal neurological status, concomitant severe disease, psychiatric illness, current psychotherapy, pathological lumbosacral anterior- posterior and lateral X-rays (except for minor degenerative changes), rheumatic inflammatic disease | Mean age (SD): IG1 = 47.9 (11. 1), IG2 = 49 (9.4), CG = 47.5 (8.9) yrs % of male: NR Racial composition: NR Work status: Employed, n (%):107 (81.4%) Other socio-demographics: Married: 74.8% Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: IG1 = 4 (10), IG2 = 2 (4.4), CG = 4 (10.9) | Cause of Pain: N-S Duration of Pain: Chronic, IG1 = 8.7 (7.7), IG2 = 9.5 (8.3), CG = 10.6 (8.7) yrs Severity of pain (Grading): NR Co-interventions: a nalgesic Med use, n (%): IG1 = 24 (60), IG2 = 20 (44.4), CG = 22 (47.8) | Groups IG1 (n = 40)– Body and ear Acu+ Physio: 20 fixed body acupoints) and 6 on the ear (alternately on one ear); 20 sessions total, 5 tx/wk for first 2 wks and once/wk for next 10 wks Drop outs: A-B = 5, E= 2 IG2 (n = 45) – Physio: According to Bruggar-concept, aim was to remove a muscle imbalance through special training of proper posture and motion; total of 26 sessions, 30 min/tx over 12 wks Drop outs: A-B = 5, D= 9 CG (n = 46) – Sham-Acu + Physio: Needles were inserted superficially, 10-20 mm distant to the verum- acupoints, outside the meridians, and were not stimulated (no “de qi”); as other groups Drop outs: A-B= 7, D = 9 | Outcome instruments: Pain: 10cm VAS; Pain Disability Index Results: Baseline: Pain: IG1 = 4.8 (1.8), IG2 = 5.3 (1.8), CG = 5.4 (1.9) P = 0.0009; IG1 = 25.2 (13.4), IG2 = 25.5 (10.4), CG = 24.9 (13.7) P = 0.0001 Immediate post tx: Pain: NR Short term: P value: IG1 = 1.8, IG2 = 2.2, CG = 2; IG1 = 12.5, IG2 = 11.3, CG = 10 Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NA Results: Baseline: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: painfulness of acu (2), problem with circulation (1), IG1 = 7.5%
Li, N (2005)38 Country: China Quality score: 4/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 4 wks Final assessments: immediately post tx N screened: 60 N randomized: 60 N completed tx:60 N attended last fu: NR Inclusion: LBP and duration of pain >1 yr; age: 18- 70 yrs; Oswestry LBP disability index > 30; Pts adhere to be follow-up Exclusion: Infection, tumor, osteoporosis, rheumatoid arthritis, fracture, radiating pain | Mean age (SD/range): IG = 57 (16) vs. CG = 56 (19) yrs % of male: IG = 38.7%; CG = 48.3% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Chronic (>1yr), IG = 7.4 (5.3) yrs; CG = 8.1 (5.7) yrs Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 31)– Acupuncture: acu at Shenyu, Dachangyu, Ashi, Weizhong, Chengshan, Kunlun, Fuliu; 35min/d x 5/wk x 4 Drop outs: 0 CG (n = 29) – Physiotherapy: light, electricity, heat; same as IG Drop outs: 0 | Outcome instruments: Pain: Ovarall efficiency(B); Relapse rate(D) Disability: Oswestry LBP disability index(A,B) Results: Baseline: Pain: NR; NR Disability: IG = 38.58 (5); CG = 40.24 (5.8) Immediate post tx: Pain: NR; NR Disability: IG = 11.55 (3.24); CG = 18.83 (5.24) Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Results: Immediate post tx: NR Short term: NR Intermediate: NR Long term: NR Harms: NR Summary of results (if provided) Acupuncture is better than hysiotherapy
MacDonald, AJR (1983)39 Country: England/UK Quality score: 2/13 Initial of reviewer: SG | Trial Design RCT Tx duration: NR Final assessments: immediately post tx N screened: NR N randomized: 17 N completed tx: NR N attended last fu: NR Inclusion: Patients with CLBP which had failed to derive relief from conventional methods; referred back pain for at least one yr. Exclusion: NR | Mean age (SD/range): NR % of male: IG = 25% vs. CG = 33% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Mixed-Specific, NR Duration of Pain: Chronic, NR Severity of pain (Grading): VAS rating 0-10 (measurement of pain; pain relief) Co-interventions:Asked to continue existing drug regimens and other forms of support as required | Groups IG (n = 8)– Acu: TPs found by palpation 30-guage(0.32mm diameter) needles inserted to depth of 4mm for 5 min for 1^st^ tx to provide noxious stimulus, doubled if failed, E-acu performed if failed; 1tx/wk, increased as required Drop outs: NR CG (n = 9) – Placebo: TPs found by palpation and standard electroenceplalographic electrodes (1cm in diameter) were attached over tender regions. The electrodes were attached by wires to the apparatus. Tx time was doubled if no beneficial results produced; same as IG Drop outs: NR | Outcome instruments: Pain: numerical scale: 1 - 3 improvements recored as minimal (1 - 24%), moderate (25-49%), good (50-74%) and excellent (75-99%) Results: Immediate post tx: proportion with pain relief: 77.35 vs. 30.14 pain score reduction (%): 57.15 vs. 22.74 activity pain score reduction (%): 52.04 vs. 5.83 Physical sign reduction (%): 96.78 vs. 29.17, p < 0.01 Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Other: Combined average reduction (%) Immediate post tx: 71.7 vs. 21.35 Short term: NR Intermediate: NR Long term: NR Harms: NR
Mendelson, G (1983)40 Country: Australia Quality score: 6/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 4 wks Final assessments: immediately post tx N screened: NR N randomized: 77 N completed tx: 72 N attended last fu: NR Inclusion: CLBP, no litigation or compensation claims pending, no overt psychiatric illness, ability to read and write in English Exclusion: NR | Mean age (SD/range): IG = 54.5 (11.8), CG = 53.6 (11.9) % of male: IG = 52.8%, CG = 43.9% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: 13 for both groups Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: NR Duration of Pain: Chronic, IG = 12.3 (10.9), CG = 12.1 (10.8) yrs Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 36)– Acu: pt prone, needles inserted: for LBP, points 23,25,36 & 40 on urinary bladder meridian; if sciatica present, points 30, 34,39 & 60 on gallbladder meridian. Needles stimulated mentally until “the ‘chi” sensation of heaviness and numbness elicited, then left for 30 min, avg of 8needles/tx; 30 min/tx, 2tx/wk for 4 wks Drop outs: A=? B=5 (total for both groups) CG (n = 41) – Placebo: intradermal injection of 2% lidocaine given at non-acu, non-tender sites in lumbar area, acu needles superficially inserted into infiltrated areas for 30 min, similar n of needles used; same as IG Drop outs: see IG | Outcome instruments: Pain: 1)VAS 100mm for pain (0-100) (A, B); McGill Pain Questionnaire (PRI, PPI) (A, B) Results: Baseline: Pain: VAS: IG = 50.5 (20.4), CG = 53.7 (25) Immediate post tx: Pain: VAS: IG = 30.2 (18), CG = 40 (24.3) (P<0.001) McGill(PRI)-mean: IG = 38%, CG = 42%; McGill (PPI)-mean: IG = 27%, CG = 30% Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NA Other: Results: Baseline: NA Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR
Mendelson, G (1978)41 Country: Australia Quality score: 1/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 4 wks Final assessments: immediately post tx N screened: NR N randomized: 77 N completed tx: NR N attended last fu: NR Inclusion: CLBP, no Litigation or compensation claims pending, no overt psychiatric illness, fluent in English, referred by their attending doctor Exclusion: NR | Mean age (SD/range): 53.5 yrs(of both groups) % of male: 48% total Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: NR Duration of Pain: Chronic, 11.7 yrs(for both groups) Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 36)– Acu: Inserting a N of needles intramuscularly in the LB region and stimulating them manually; 30 min/tx, 2 tx/wk for 4 wks Drop outs: NR CG (n = 41) – Placebo: Acu needles were inserted subcutaneously, a small amount of local anesthetic was injected through them and the needles were not stimulated; same as IG Drop outs: NR | Outcome instruments: Pain: VAS 100mm for pain (0-100) (A, B) Results: Baseline: Pain: IG = 50.8 (20.4), CG = 52.3 (24.3) Immediate post tx: Pain: IG = 35 (22.2), CG = 38.5 (26.9) Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NA Results: Immediate post tx: NR Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: No raw data reported for the following outcomes:; 1. McGill Pain Questionnaire; 2. Analgesic Intake; 3. Spinal Mobility; 4. Subjective rating of pain and disability
Meng, CF (2003)42 Country: NY-US Quality score: 7/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 2 wks Final assessments: immediately post tx N screened: 250 N randomized: 55 N completed tx: 55 N attended last fu: 55 Inclusion: chronic N-S LBP > 12 wks; age 60 yrs or more; radiography within past yr Exclusion: S LBP; lumbar surgery; prior use of acu; use of corticosteroids, muscle relaxants, narcotics, anticoagulants, epidural steroid injections within past 3 mo | Mean age (SD/range): IG = 72 (5) vs. CG = 70 (6) yrs % of male: IG = 42%, CG = 37.5% Racial composition: 84.7% Caucasian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S % S: buttock pain: IG = 48.4%, CG = 25% Duration of Pain: chronic, IG 12 (16), CG = 12 (14) yrs Severity of pain (Grading): NR Co-interventions: Nsaids: Non-narcotic analgesic agents: aspirin: Muscle Relaxants | Groups IG (n = 31)– Acu: aseptic technique and disposable, sterile needles .. Deqi sensation; ES 4-6 Hz; 10-14 needles; 20 minutes; acu protocol; biwkly 5 sessions, 10 sessions total Drop outs: NR CG (n = 24) – Usual care: NSAIDs, analgesics, EXs; NR Drop outs: NR | Outcome instruments: Pain: VAS- word anchors (ITT) Disability: mRDQ-(ITT) Results: Baseline: Pain: IG = 1.6 (1); CG = 1.7 (1) Disability: IG = 9.8 (3.6); CG = 11.8 (5.3) Immediate post tx: Pain: IG = 1.6 (NR); CG = 1.1 (NR) Disability: IG = 13.1; CG = 12.4 Short term: VAS: IG = 1.4 (NR), CG = 2.4 (NR); RDQ: IG = 6.3 (4.4), CG = 11.4 (4.8) Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Results: Immediate post tx: NR Short term: NR Intermediate: NR Long term: NR Harms: NR Summary of results (if provided): acu is effective, safe adjunctive tx for CLBP in elderly-small sample size study.
Molsberger, AF (2002)43 Country: Germany Quality score: 3/13 Initial of reviewer: SG | Trial Design RCT Tx duration: NR Final assessments: 3 mos N screened: NR N randomized: 186 N completed tx: 174 N attended last fu: 186 Inclusion: pain for at least 6 wks; average pain score of at least 50mm on a 100mm VAS during the last wk, age 20 - 60 yrs, the ability to communicate in German Exclusion: sciatica or other neurological disorders; history of disc or spine surgery; systematic bone and joint disorder | Mean age (SD/range): IG1 = 49 (8), IG2 = 50 (6), CG = 49 (7) yrs % of male: IG1 = 44.6 – 53.3% Racial composition: NR Work status: NR Other socio-demographics:# of d in hospital: IG1 = 31.4 (5.4), IG2 = 32.4 (6.2), CG = 31.7 (5.8) Co morbidities:NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Chronic, IG1 = 11.5 (9.2), IG2 = 9.9 (7.7), CG = 8.1 (5.7) Severity of pain (Grading): NR Co-interventions: % of pts with diclofenac intake: IG1 = 18%, IG2 = 20%, CG = 15% | Groups IG1 (n = 65)– Verum acu+conventional orthopedic therapy. Always a numb, warm feeling around the acu point (Deqi) was achieved; 30min/tx, 3tx/wk Drop outs: B = 7, C = 11 IG2 (n = 61)– Sham Acu+ conventional orthopedic tx: 10 needles applied at depth < 1 cm at lumbarnon-acu points, and 5 needles on either side of the back; same as IG1 Drop outs: B = 3, C = 17 CG (n = 60) – nil + conventional orthopedic therapy: daily PT, physical EXs, back school, mud packs, infrared heat therapy. 50mg diclofenac on demand up to 3 /d; NR Drop outs: B = 2, C = 22 | Outcome instruments: Pain: VAS: mean pain intensity (ITT) Disability: NA Results: Baseline: Pain: IG1 = 68 (17), IG2 = 64 (11), CG = 67 (14) Disability: NA Immediate post tx: Pain: IG1 = 26 (21), IG2 = 36 (19), CG = 39 (21); N of pts with >50% pain reduction: IG1 = 65%, IG2 = 34%, CG = 43% Disability: NA Short term: IG1 = 23 (20), IG2 = 43 (23), CG = 52 (19) N of pts with >50% pain reduction:IG1 = 77%, IG2 = 29%, CG = 14% Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NA Results: Immediate post tx: NR Short term: NR Intermediate: NR Long term: NR Harms: NR Summary of results (if provided): night pain (n of no ro mild/no of moderate to severe):IG1 = 31/28, IG2 = 28/32, CG = 23/36
Sakai, T (1998)44 Country: Japan Quality score: 0/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 2 wks Final assessments: Post-tx N screened: NR N randomized: 26 N completed tx: 26 N attended last fu: 26 Inclusion: N-S LBP Exclusion: osteoarthritis of lumbar-spine, osteoporosis, other S causes of pain; diabetes or malignancy; increase of CRP or ESR; Med of corticosteroid, immunosuppressant agent, NSAID or muscle relaxant; problem of general condition; dementia; pregnancy; elderly pt. | Mean age (SD/range): IG = 50.8 (18.1) vs. CG = 53.8 (8.5) yrs % of male: IG = 28.6%, CG = 25% Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Chronic, IG = 92.5, CG = 25.5 Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 14)– Acupuncture: There is no information about stimulation technique and insertion depth. Needling points in lumbar part were chosen from BL23, 25, 32, 52 and 2 extra channel points, and that in L/E were chosen from BL37, 40, 57, ST36, GB34 by palpation. Acupuncture tx was performed 3 times; 2 tx/wk, 2 wks, 4 tx total Drop outs: NR CG (n = 12) – Medication (NSAID): Medication which includes NSAID or kampo medicine; NR Drop outs: NR | Outcomes: Pain: Subjective symptoms in JOA score(3 pt); Pain relief score Disability: ADL in JO score (14 pt) Results: Baseline: Pain: IG = 1.3 (0.5), CG = 1.4 (0.5); IG = 10 (0) Disability: IG = 7.6 (2.3), CG = 10.3 (1) Immediate post tx: Pain: IG = 2.4 (0.5), CG = 2.5 (0.5); IG = 2.3 (1.5) Disability: IG = 12.1 (2), CG = 13.3 (0.8) Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: Other: NA Results: Immediate post tx: NR Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: Duration of LBP in acu group may be longer than that in Med group. ADL score in JOA score in acu group was lower than that in Med group, disability in acu group may be more severe than that in Med group
Sator-Katzenschlager, SM (2004)45 Country: Austria Quality score: 9/13 Initial of reviewer: SG | Trial DesignRCT- Tx duration: 6 wks Final assessments: immediately post tx N screened: 87 N randomized: 61 N completed tx: 55 N attended last fu: NR Inclusion: Lumbar LBP of at least 6 mo, normal neurologic function of lumbosacral nerves, no pain radiation, persisting pain intensity VAS => 5 despite after taking therapy with lornoxicam and tramadol Exclusion: Allergy against lornoxicam or tramadol, history of drug abuse, pregnancy, concomitant use of TENS or pacemaker, history of Acu | Mean age (SD/range): IG = 54.1 (12.3) vs. CG = 53.1 (12.1) yrs % of male: 0.3% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: 36 pts had LBP of muscular origin, 25 pts had additional severe skeletal changes on radiograph/reso nance imaging of spine, including spondylarthrosis and localized disc protrusion Duration of Pain: Chronic, 4.6 (1) yrs Severity of pain (Grading): VAS ≥ 5 Co-interventions: NR | Groups IG (n = 31)– Auricular E-Acu: frequency of stimulation was 1 Hz, high phase was from 1 to 10 ms. After 3 hrs of stimulation, 3 hrs break, max current: 4 mA and Titan needles (27-gauge, 3 mm length) inserted in lumbar spine, 40; shen men, 55; and cushion 29; 48hrs/session, 1 session/wk for 6 wks Drop outs: 2 CG (n = 30)– Auricular Acu: same as IG Drop outs: 4 | Outcomes: Pain: Pain intensity (VAS) = numerical data NR Disability: NA Results: Baseline: Pain: NR Immediate post tx: Pain: NR Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: QOL, well being = numerical data NR Return to work: Immediate post tx: NR Short term: NR Intermediate: NR Long term: NR Return to work 10 (77%) vs. 3 (25%) Harms: NR Summary: Decrease in pain intensity significantly greater in E-Acu vs. Acu. Increase in psychological well-being, physical activity, and quality of sleep greater in E-Acu vs. Acu.
Takeda, H (2001)46 Country: Japan Quality score: 5/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 3 wks Final assessments: immediately post tx N screened: NR N randomized: 20 N completed tx: 18 N attended last fu: NR Inclusion: Students of acu college who are suffering from lumbago Exclusion: no information [students who have sciatica(info from author)] | Mean age (SD/range): IG = 26.4 (6.4) vs. CG = 35.8 (9.3) yrs % of male: ratio: IG – 8/2, CG – 9/1, majority male Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Chronic, IG = 40.4 (75.9); CG = 810 (76.5) mos Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 10)– Distal point needling: acupoints in lumbar area: BL23 and EX-B7, mimicked needle insertion:tapped head of needle guide tube, gesture of needle performed. Acu points in BL37, 40 and 58 needles by real acu needle (40 mm in length and o.2 mm in diameter) insertion depth of 1-2 cm, sparrow pecking techn. Done 5 times then removed; 2tx/wk for 3 wks Drop outs: 1 CG (n = 10) – Lumbar area needling: same point in lumbar area needled by real acu needle, same needles as IG used, sparrow pecking tech. 5 times, same acupoint for lower extremity mimicked needle insertion: tapped head of needle guide tube, gesture needling performed; same as IG Drop outs: 1 | Outcome instruments: Pain: VAS; PPT threshold at lumbar; PPT threshold at foot Disability: ADL score Results: Baseline: Pain: IG = 35.9 (16.2), CG = 27.4 (21.9); IG = 5.2 (3.3), CG = 6.6 (2); IG = 2.4 (1.6), CG = 3 (1.1) Disability: IG = 13.9 (2), CG = 14.2 (2.5) Immediate post tx: Pain: IG = 28 (24.3), CG = 17 (20.9); IG = 5.3 (3.3), CG = 6.5 (2.1); IG = 2.7 (2), CG = 2.7 (1.5) Disability: IG = 14.4 (1.6), CG = 15 (1.4) | Outcome instruments: QoL/ well being: Results: Immediate post tx: NR Short term: NR Intermediate: NR Long term: NR Harms: NR
Thomas, A (1994)47 Country: Sweden Quality score: 4/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 6 wks Final assessments: 6 mos N screened: NR N randomized: 43 N completed tx: 40 N attended last fu: NR Inclusion: pts with chorinc LBP treated at two clinics; sudden or insidious onset of LBP with or without trauma; duration > /= 6 mo; remissions and occasional pain free intervals; recurrences with pain of variable intensity; Exclusion: major depressive illness or neurosis, past back surgery; other significan systemic or neurological disorders | Mean age (SD/range): NR % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Osteroarthiris of lumar, or sacrolilac joint with sciatica, intervertebral disc degeneration, lubar strain with sciatica, osteoporosis with dorsolumar strain; chronic disc prolapse; chronic lumbar strain Duration of Pain: chronic (at least 6 mos) Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 33)– Acu: ME of needles, low freq. e-stimul. At 2Hz and high freq. at 80 Hz 3 tx, each 30 min of MS, LFES or HFES, then continued tx with preferred mode for 6 wks Drop outs: A = 3 CG (n = 10) – Waiting list: NR; NR Drop outs: 0 | Outcomes: Pain: activities with < 50% pain- no numerical data- p values reported Short term: NR Intermediate: NR Long term: NR Note: data is presented in bar graphs and not extracted in this report. | Outcome instruments: QoL/ well being: Other: ROM Results: Immediate post tx: no numeric data provided Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: Results suggest that 2Hz ES is the mode of choice when using acu in the tx of chronic nociceptive LBP
Tsui MLK (2004)48 Country: China Quality score: 6/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 4 wks Final assessments: 3 mos N screened: NR N randomized: 42 N completed tx: 42 N attended last fu: 42 Inclusion: Pts aged 20-55 yrs with LBP radiating down to the thigh or calf for => 3 mo mechanical cause but not from cancer or TB, with positive SLR findings Exclusion: Repeated history of LBP, hip/back previous surgery, spinal stenosis with claudication, spine fracture, systemic arthritis, spondylolisthesis grade 3-4,osteoporosis | Mean age: 40.0 yrs % of male: IG1 = 24%, IG2 = 29%, CG = 40% Racial composition: All Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: Mechanical conditions but not cancer Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: NR Duration of Pain: Chronic, NR Severity of pain (Grading): NR Co-interventions: in structed to perform same set of back EX as in the Exercise group; analgesics | Groups IG1 (n = 14)– E-acu: dual channel machine with freq. of 1 Hz-999 Hz, 4 local points over bilateral side of LB and 2 over the buttock/ leg, needles inserted to achieve “de qi”, needles in acu points BL-26 and GB-30 were attached to the machine; 2 tx/wk for 4 wks, 8 sessions total each 20 min Drop outs: 3 total NR IG2 (n = 14) – E-heat acu: machine used to produce heat + needles, 4 channels delivered 38-48°C, same acupoints as IG1; same as IG1 CG (n = 14) – Exercise: back Mob and abdominal stabilization; 6 BM x 20, 1 AS x 10, 3 times/d | Outcomes: Pain: Pain intensity (VAS) Disability: RMDQ Results: Immediate post tx: Pain: IG1 = 3.07 (1.9), IG2 = 2.86 (1.75), CG = 5.5 (1.83) Disability: IG1 = 8.57 (4.01), IG2 = 7.93 (5.14), CG = 9.36 (3.56) Short term: VAS- IG1 = 2.43 (1.87), IG2 = 2.27 (2.15), CG = 5.21 (1.88) P = 0.001 RMDQ – IG1 = 7.64 (3.75), IG2 = 8.36 (4.65), CG = 8.79 (3.4) Intermediate: RMDQ – IG1 = 5.93 (3.79), IG2 = 8 (5.66), CG = 8.57 (3.48) | Outcome instruments: QoL/ well being: NA Results: NA Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR
Witt, CM (2006)49 Country: Germany Quality score: 7/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 3 mos Final assessments: 1 yr N screened: 11630 N randomized: 2840 N completed tx: 2840 N attended last fu: 2518 Inclusion: clinical diagnosis of CLBP lasting more than 6 mo; aged ≥ 18, provision of written informed consent Exclusion: protusion or prolapse of one or more intervertebral discs with concurrent neurologic symptoms; other S causes of pain | Mean age (SD/range): IG = 53.1 (13.5) vs. CG = 526 (13.2) yrs % of male: IG = 42.3%; CG = 43.1% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Chronic, IG = 7.2 (8) yrs; CG = 7.2 (7.8) yrs Severity of pain (Grading): NR Co-interventions: usual care | Groups IG (n = 1451) –Acu: disposable needles- at acu points decided by the treating physician; 3 mo tx phase, max 15 tx, 74% received 5-10 sessions, 21 received>10 sessions, 5% received< 5 sessions Drop outs: C = 88, D= 130 CG (n = 1390) –Control: NR; 3 mo tx phase Drop outs: C = 130, D = 193 | Outcomes: Pain: BP score Disability: Back function; HFAQ Results: Baseline: Pain: mean-change from A: IG = 37%; CG = 9.8% Immediate post tx: Pain: --- Disability: Mean change from A: IG = 33.3%, CG = 11.3%; IG = 12.1, CG = 2.7 Short term: Pain: IG = 33.5%, CG = 30.8% Intermediate: NR Long term: NR | Outcomes: QoL/ well being: SF-36- health related QoL A, B, C Results: Baseline: IG = 34.3 (9), CG = 34.6 (9.6) (P<0.001) Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR
Yeung, KN (2003)50 Country: Hong Kong Quality score: 7/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 4 wks Fu duration (last assessment: 3 mos N screened: NR N randomized: 52 N completed tx: 52 N attended last fu: 49 Inclusion: pts with chronic N-S LBP (> 6 mo) with or without radiation- aged 18-75 yrs Exclusion: structural deformity (ankylosing spondylitis, scoliosis); lower limb fracture; tumors; spinal infection; caudaequina syndrome; pregnancy; spinal cord compression; pts unable to keep appointments; receiving acu tx within the past 6 mo; receiving physio tx within the past 3 mo | Mean age (SD/range): IG = 50.4 (16.3) vs. CG = 55.6 (10.4) yrs % of male: IG = 15.4%; CG = 19.2% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S(CG = 12% with prolapsed disc) % NS:14 (53.8%) Duration of Pain: Chronic, NR Severity of pain (Grading): NR Co-interventions: analgesic use: IG =3.8%, CG =0% other tx (tui na, massage, chiropractor, bone setter or corset):IG = 5 (19.2%), CG = 6 (23.1%) | Groups IG (n = 26) – Acu + EX: E-Acu points: BL23, BL40, and SP6. Needles applied to ipsilateral pain side needles, #30 (0.3 mm) 40 mm long needles inserted and manipulated until Teh Chi obtained. Stimulation on needle sat a freq of 2Hz for 30 min-n the intensity of stimulation set at tolerable to the Pts and often with evoked visible muscle contraction; 3times/wk for 4 wks Drop outs: C = 2 CG (n = 26) – Exercise: Standard group EX program, back strengthening and stretching EXs; 1 hr session/wk for 4 wks Drop outs: C = 1 | Outcomes: Pain: NRS: avg pain; worst pain Disability: Aberdeen LBP scale Results-Baseline: Pain: IG = 6.38 (1.77), CG = 5.88 (1.84); IG = 6.65 (1.77), CG = 6.5 (1.56) Disability: IG = 35.32 (11.72), CG = 32.49 (13.79) Immediate post tx: Pain: IG = 3.81 (2.1), CG = 5.12 (2.18); IG = 3.92 (2.43), CG = 5.35 (2.04) Disability: IG = 20.02 (10.41), CG = 30.82 (13.03) Short term: Aberdeen: IG = 19.86 (10.12), CG = 25.82 (13.11) Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NA Results: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: 1 Pt- stroke before 3 mos fu
Yu, W (1997)51 Country: China Quality score: /13 Initial of reviewer: SG | Trial Design RCT- Tx duration: 10-20 ds Final assessments: immediately post tx N screened: Don’t know N randomized: 200 N completed tx: 200 N attended last fu: NR Inclusion: pain in waist and leg Exclusion: NR | Mean age (SD/range): NR % of male: NR Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S with leg pain Duration of Pain: >6 mos Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 103) – Acu local point: eletro-acu, local pain point, retention 30 min; 1 tx/d, 20 tx/course, 1-2 courses Drop outs: B=0 CG (n = 97) – Acu local point and weizhong point: eletro-acu, local pain point + weizhong, retention 30 min; same as IG Drop outs: B=0 | Outcomes: Pain: NA Disability: NA Results: NA Baseline: Pain: Immediate post tx: NA Pain: Disability: Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: well being, B Results: Immediate post tx: N (%) improved – IG = 99 (96.1 %), CG = 86 (88.7%) P<0.01 Short term: NR Intermediate: NR Long term: NR Harms: NR
Yuan, J (2009)52 Country: UK Quality score: 9/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 5 and 2 wks Final assessments: 1 yr N screened: NR N randomized: 30 N completed tx: 30 N attended last fu: 21 Inclusion: Subjects with chronic NS LBP Exclusion: Infection, tumor, osteoporosis, fracture, structural deformity, inflammatory disorder, radicular syndrome or cauda equina syndrome | Mean age (SD/range): 43.53 (9.67) vs. 43.87 (10.45) yrs % of male: 60% in both groups Racial composition: NR Work status: employed (%): 7 vs. 13 Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Non S % NS: all Pts Duration of Pain: 14.2 vs. 11 yrs Severity of pain (Grading): NR Co-interventions: pts taking Med (%): 33 vs. 20 | Groups IG (n = 15)– Acu-traditional Chinese methode, needles 0.25 mm x 0.25 mm x 50 mm. manually stimulated to produce ‘de qui’ sensation, retained for 20-30 min; 2x / wk for 5 wks Drop outs: 1 at 2, 5 and 12 wks; 4 at 1 yr fu IG2 (n = 15) – Acu-traditional Chinese acu method as IG1, 5x/wk for 2 wks Drop outs: 5 at 1 yr fu | Outcome instruments: Pain: VAS (0 – 10) Disability Results: NA Baseline: Pain mean (95% CI) average pain: 4.30 (3.06, 5.53) vs. 3.98 (2.87, 5.10) Disability (RMDQ): 6.40 (4.37, 8.43) vs. 7.80 (5.41, 10.19) Immediate post tx: Pain: NR Short term: NR Intermediate: NR Long term: NR Note: only baseline values are reported. Outcome results for immediate, short term and long term fu are presented in graphs and not extracted in this report | Outcome instruments: QoL/ well being: Data in graph Other: NA Results- mean (95% CI) : Baseline: “QOL: 2.20 (1.72, 2.68) vs. 2.86 (2.07, 3.65) Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: minor bleeding 4 vs. 7; pain: 2 vs. 0 Tiredness or other discomfort: 1 vs. 4 Summary: There were no significant differences betweenthe groups in terms of any of the outcomes, (Pain, Disabiltiy, well being) at each follow-up time point.

Table 1.5 Low Back Pain - Acupuncture - Mixed duration- Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Chen, MZ (2005)53 Country: China Quality score: 4/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: 10 ds Final assessments: immediately post tx N screened: 90 N randomized: 90 N completed tx:90 N attended last fu: NR Inclusion: L4,L5 spinal stenosis; pain threshold 0.4-1.8 mA Exclusion: disc herniation, bone TB, tumor; pain threshold < 0.4 mA | Mean age (SD/range): IG1 = 34.24 (5.78); IG2 = 33.36 (7.58); IG3 = 35.78 (9.65) yrs % of male: 70% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Spinal stenosis Duration of Pain: Unknown or mixed duration: IG1 = 5.25 yrs (3.95); IG2 = 5.78yrs (4.87); IG3 = 4.71 yrs (3.96) Severity of pain (Grading): NR Co-interventions: NR | Groups IG1 (n = 30) –Acu warming needle + oral nimeisulide; acupoint injection of anisodamine; 15-30 min.d for 10 ds Drop outs: A = 0, B= 0 IG2 (n = 30) – Oral Med: oral nimeisulide tablet; 0.1 bid for 10 ds Drop outs: NR IG3 (n = 30) – acupoint injection: of anisodamine <10 mg/d x 10 ds Drop outs: NR | Outcomes: Pain: Pain threshold(A,B) Disability: NR Results: Baseline: NR Pain threshold: IG1 = 0.98 (0.27); IG2 = 1.04 (0.27); IG3 = 0.86 (0.22) Immediate post tx: Pain threshold: IG1 = 2.62 (0.59); IG2 = 1.54 (0.39); IG3 = 1.58 (0.22) Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Results: Baseline: NA Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR Summary of results (if provided): warming needle is better than oral medicine and acupoint injection
Chen, X (2007)54 Country: China Quality score: 3/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: not clear Final assessments: immediately post tx N screened: not mentioned N randomized: 88 N completed tx: 88 N attended last fu: NR Eligibility criteria:; - inclusion: diagnosed using Chinese Medical Diagnostic and therapeutic Effective Standard CT exmination showed lumbar intervertebral Disc Protrusion; - exclusion: spinal stenosis, myofacial , Mawei nerve pain, tumor ... etc. | Mean age (SD/range): NR % of male: IG = 52.3%; CG = 56.8% Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc/joint disease Duration of Pain: IG - 5d to 5yr: acute, subacute, chronic; CG - 7d to 4 yr: acute, subacute, chronic Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 44)– Deep Acu of lumbar kiaji points: acupoint: Jiaji, deeply acu 3 inches retention 20min; 10 tx/course, 3 d rest between courses x 2 courses Drop outs: B =0 CG (n = 44) – Conventional Acu of jiaji point: retention 20 min, normal depth; 11 tx/course, 3 ds between courses x 3 courses Drop outs: B =0 | Outcomes: Pain: NA Disability: NA Results: Baseline: NA Pain: Immediate post tx: NA Pain: Disability: Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: well being, B, based on Chinese Medical Diagnostic and therapeutic Effective Standard Results: Immediate post tx: IG = 95.5%, CG = 77.3% improved Short term: NR Intermediate: NR Long term: NR Harms: NR Summary (if provided): Deep acu of lumbar jiaji points has a good curative effect on lumbar intervertebral disc protrusion.
Cu, J (2004)55 Country: China Quality score: 4/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: 20 ds Final assessments: immediately post tx N screened: not mentioned N randomized: 50 N completed tx: 50 N attended last fu: NR Eligibility criteria: - Inclusion: Chinese Medical Diagnostic and Therapeutic Standard. - exclusion: Pts with severe nerve function defeat, caudal nerve was pressed, and who is suitable for surgery | Mean age (SD/range): IG = 41.4 vs. CG = 43.6 yrs % of male: IG = 56% vs. CG = 60% Racial composition: Asian Work status: NR Other socio-demographics: Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc/joint disease Duration of Pain: acute, subacute, chronic, NR Severity of pain (Grading): Co-interventions: NR | Groups IG (n = 25) – Scalp acu + massage: 0.35 mmX75 mm needle, severe pain, retention 24hrs massage: elbow point massage ,2 palms massage lumbar muscle, 2 twists press muscles on 2 sides of spine, thumb massage buttock muscle, traction, etc; 1 tx/d, 10tx/course, 3 ds between courses x 2 courses Drop outs: B=0 CG (n = 25)– Massage: same as IG; same as IG Drop outs: B=0 | Outcomes: Pain: NA Disability: NA Results: Baseline: NA Pain: NA Immediate post tx: NA Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: Chinese Medical Diagnostic and therapeutic Standard Results: Immediate post tx: IG = 96%, CG = 88% improved (P<0.01) Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: IG has an obvious therapeutic effect on prolapse of lumbar intervertebral disc and they exert the therapeutic effect possibly through regulative action on immune functions
Ding, X (2002)56 Country: China Quality score: 3/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: 28 ds Final assessments: immediately post tx N screened: Don’t know N randomized: 68 N completed tx:68 N attended last fu: NR Eligibility criteria:; - inclusion:; 1. Diagnosed as intervertebral disc protrusion; 2. Only one side is in pain; 3. Who has obvious 1 or 2 sympotoms: can not go to sleep, turn aside, walk, caugh,sneeze, bowel movement, bend waist because of the pain; 4. Pain in waist 1 Jiaji and waist 5 jiaji is in the healthy side. and pain rate is ++ above; - exclusion: NR | Mean age (SD/range): NR % of male: IG = 32.4%; CG = 35.3% Racial composition: NR Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc/joint disease Duration of Pain, range: IG - 7ds-2 yrs: acute, subacute, chronic; CG - 7ds-1.5yrs: acute, subacute, chronic Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 34)– injection + acu on healthy side: 0.3mmX 75mm needle, injection on healthy side and acu on affected side, 100mg Vitamin B1 +0.2 mg Vitamin B12 injection in Jiaji.; 1 tx/d for 5 ds, 2 ds rest, 20 tx total Drop outs: 0 CG (n = 34) – injection +acu on affected side: both injection and acu on affected side, 100mg Vitamin B1 +0.2 mg Vitamin B12 injection in Jiaji; 2 tx/d for 5 ds , 2 ds rest, 20 tx total. Drop outs: 0 | Outcomes: Pain: NR Disability: NR Results: Baseline: NA Pain: Immediate post tx: NA Pain: - Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: well being (cure effect) Results: Immediate post tx: IG = 82.4%, CG = 14.7% Short term: NR Intermediate: NR Long term: NR Harms: NR Summary (if provided): contralateral acu has a better effect for protrusion of intervertebral disc accompanied by tenderness on Jiaji points on the healthy side than routine acu on the affected side
Ding, Y (1998)57 Country: China Quality score: 3/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: not clear Final assessments: immediately post tx N screened: not mentioned N randomized: 54 N completed tx: 54 N attended last fu: NR Eligibility criteria:; - inclusion: LBP repeatedly occur, lumbar sacrum pain become worse with fatigue; X-ray and examination exclude the other disease the LBP caused by Qi and blood stagnant.; - exclusion: NR | Mean age (SD/range): IG = 45 vs. CG = 42 yrs % of male: IG = 80% vs. CG = 63.2% Racial composition: Asian Work status: NR Other socio-demographics: Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Lumbar muscle strain Duration of Pain: IG = <1 yr to >6 yr, CG = NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 35) – fly-probing- acupoint manipulation: major acupoint: yaoyangguan, ashi supplement acupoint: weizhong 0.38 mmx75 mm needle, when getting qi, use flying-probing acupoint manipulation retention 40-50 min; 1tx/d, 10tx/course Drop outs: B=0 CG (n = 19)– Routine acu: acupoints as above, when getting qi, retention 20 min; same as IG Drop outs: B=0 | Outcomes: Pain: NA Disability: NA Results: Baseline: NA Pain: NA Immediate post tx: NA Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: well being Results : Immediate post tx: IG = 94.3%, CG = 73.7% improved (P<0.01) Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: fly-probing-acupoint manipulation as a main acu tx has a stronger effect in promoting the flow of qi and produced a better effect in stransverse oscillatory rotping pain.
Guo, W (2005)58 Country: China Quality score: 4/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: NR Final assessments: immediately post tx N screened: 197 N randomized: 197 N completed tx: 197 N attended last fu: NR Inclusion: Disc herniation; age:20-70 yrs; Diagnosed by CT or MRI; Clinical Positive Signs Exclusion: pregnant and breast-feeding women; Serious cardiovascular and cerebrovascular diseases; Serious liver and kidney disease; Serious infecton; Lumbar TB or tumor; Gastrointestinal disease | Mean age (SD/range): IG = 43(11.33) vs. CG = 44 (10.12) yrs % of male: IG = 54%; CG = 51.5% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain Disc herniation Duration of Pain: Unknown or mixed duration, IG = 2.5 (2.44) yrs; CG = 2.41 (2.33) yrs Severity of pain (Grading): NR Co-interventions: Traction therapy | Groups IG (n = 100) – E-acu + acupoint injection: 1^st^ stage :E-acu + acupoint inject at Jiaji; 2^nd^ stage: E-acu; inject using 3ml Triamcinolone Acetonide 40mg + 20g/L Lidocaine Hydrochloride 2ml + Vitamin B12 500ug+ NS 4ml) /5d x 2 Drop outs: A = 0;B = 0 CG (n = 97) – SM or Mob + oral Med: NR; Ibuprofen Sustained Release Tablets 0.3g po.bid; Phenprobamate tablets 0.4,po.tid;Tab.Vitamin B1 20mg, tid) x 2m Drop outs: A = 0;B = 0 | Outcomes: Pain: VRS(A,B) Disability: Results: Baseline: Immediate post tx: Pain: IG = 1.32 (0.31); CG = 3.11 (0.23) (P<0.01) Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Other: Angle for SLR test Results : Immediate post tx: IG = 70 (215); CG = 50 (20) Short term: NA Intermediate:NA Long term: NR Harms: NR Summary: Electro-acupucture plus acupoint inject Med group is better than SM or spinal Mob plus oral Med group
Huang, GF (2006)59 Country: China Quality score: 6/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 20 ds Final assessments: immediately post tx N screened: 68 N randomized: 68 N completed tx:68 N attended last fu: NR Eligibility criteria:; - inclusion: Disc herniation; - exclusion: pregnant and breast-feeding women; Serious disease; mental Pts; Cauda equina compression; have other indications for surgery | Mean age (SD/range): NR % of male: IG = 58.8%, CG = NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: nR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc herniation Duration of Pain: 2d-10yr; NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 36) – Special e-acu: acu at Jiaji,Huangtiao, Yanglinqiang and Wenzhong points; 10-20mA, 30min/d*10d/course x 2 Drop outs: 0 CG (n = 32) – Routine e-acu: acu at Shenyu, Dachangyu,Xubian, Huantiao,Chengfu,Yinm en, Weizhong and Yanglinqian; same as IG Drop outs: 0 | Outcomes: Pain: VAS Results- Immediate post tx: Pain: 5.09 (0.61) vs. 6.58 (0.6) Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NA Other: overall efficacy Results: Immediate post tx: Time of analgesic effects and lasting effect was better in IG vs. CG, P < 0.01 Short term: NR Intermediate: NR Long term: NR Harms: NR Summary of results: electroaupuncture at Jiaji is better than routine acu (time of analgesic effect, and overall efficacy)
Huang, GF (2006)60 Country: China Quality score: 6/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 24 ds Final assessments: Post-tx N screened: 90 N randomized: 90 N completed tx: 90 N attended last fu: 90 Inclusion: Disc herniation; aged 18-65 yrs; Diagnosed by CT or MRI Exclusion: Spondylolysis with spondylolisthesis;Serio u disease;Severe osteoporosis; Lumbar tumor and TB | Mean age (SD/range): 41.5 (13.7) yrs % of male: 51.1% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc herniation Duration of Pain: Mixed Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 45) – Acu + Spinal manipulation; acupunture at Ashi, Huantiao, Weizhong and Chenshan; 30 min/ tx, 6 tx/ course, 4 courses Drop outs: A = 0, C = 0 CG (n = 45) – Spinal manipulation: mechanical traction; 30 min/ tx, 6 tx/ course, 4 courses Drop outs: A = 0, C = 0 | Outcome instruments: Pain: VAS; Overall efficiency Disability: NR Results: Immediate post tx: Pain, mean (SD): 1.91 (0.93) vs. 3.58 (1.52), p < 0.01] Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Excellent rate Results: Immediate post tx: excellent rate: 86.6% vs. 57.78%, p < 0.01 Short term: NR Intermediate: NR Long term: NR Harms: NR Summary of results (if provided): Combinative group is better
Hua-Sheng Tang (2008)61 Country: China Quality score: 3/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 40 ds Final assessments: 6 mo N screened: NR N randomized: 165 N completed tx: 133 N attended last fu: NR Inclusion: 20-69 yrs; CLBP and/or traumatic LB injury; LBP complicated with radiant pain towards lower extremities and/or sciatica; disappearance of normal spinal curve and/or Scoliosis associated with tenderness; Straight leg raise positive; CT and/or MRI indicate Exclusion: lumber herination complicated with spondylolisthesis and/or myelocele; pregnant and postnatal woman | Mean age (SD/range): IG = 40 vs. CG = 40 yrs % of male: IG = 57.6% vs. CG = 56.2% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: 1-disc/joint disease Duration of Pain: acute; subacute (up to 12 wks); Chronic (> 12 wks); IG = 13 mo. CG = 12 mo. Severity of pain (Grading): NR Co-interventions: NR | Groups IG1 (n = 85) – Acupuncture along channel: induce “de qi” sensation using electrical impluse device connected with needles, stimulated at frq of 6-8Hz, 30 min/sess,1 sess/d x 40 ds Drop outs: D = 10 CG (n = 80) – routine acu: Selected 6-8 acupoints among BL23, 24, 25, 26, 40, 54, 60 and GB 30, 34; same as IG Drop outs: D = 22 | Outcome instruments: Pain: no numeric data Disability: no numeric data Results: Immediate post tx: Pain: NR Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Other: cured and markedly effective rate; and recurrence of pain Results: Immediate post tx: cured and markedly effective rate: 88.2% vs. 72.5%; Recurrence of pain, rate of 24% vs. 41.4% Short term: NR Intermediate: NR Long term: NR Harms: NR
Jia, Chao (2004)62 Country: China Quality score: 5/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 20 ds Final assessments: immediately post tx N screened: 82 N randomized: 82 N completed tx: 82 N attended last fu: NR Eligibility criteria: Inclusion: diagnosed as Cervical Spondylosis using ref[1] 1993-chinese, only those who were compliance with the tx, only those who reponsed to the surveys. Cause of pain: 1-Lumbar disc hemiation Exclusion: tumor, fracture, with heart, lung and kidney disease etc. | Mean age (SD/range): NR % of male: NR Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: disc/joint disease Duration of Pain: only mentioned people has pain < 6 mos and as well >6mos Severity of pain (Grading): Mcgill: PRI, PRI Co-interventions: NR | Groups IG (n = 45)– deeply-acupuncturing jiaji acupoint + acupoint-injection: 65mm, size 28 needle for acu +injection of dangui; + 2ml dangui injection 30 min/tx, 1tx/d, 10 tx/course x 2 + 2ml dangui injection 1 tx/d, 10 tx/course, total of 2 course Drop outs: 0 CG (n = 37) – acupuncturing back-shu acupoint +acupoint – injection: same as IG ; same as IG Drop outs: 0 | Outcome instruments: Pain: VAS(diff. between baseline and immediate tx)cm; Disability: NR Results: Pain, mean changes from baseline: IG = 5.18 (0.32) cm, CG = 3.84 (0.27)cm; Disability: NR Immediate post tx: NR Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: Chinese Medical Diagnostic and effectiveness standard Results: Immediate post tx: improved: 96% vs. 83% Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: The clinical effect of deep-acpuncturing jiaji acupoint +acupoint-injection is better than that of acupuncturing back-shu acupoint combined with point-injection
Li, D (2006)64 Country: China Quality score: 6/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: 2-4 wks Final assessments: 6 mos N screened: NR N randomized: 240 N completed tx: 240 N attended last fu: 240 Inclusion: pts with lumbar disc herniation Exclusion: NR | Mean age (SD/range): NR % of male: NR Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Lumbar disc herniation Duration of Pain: Mixed, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG1 (n = 80) – Traction rotator manipulation of sumbar spine tx: tx performed to the segment of the intervertebral disc herniation; once/wk, 2 wks Drop outs: 0 IG2 (n = 80) – Acu silver needle heat conductive tx: conducted to pts waist and buttocks; Same as IG1 Drop outs: 0 CG (n = 80) – Traction + needle heat: Combination of IG1 and IG2; each tx method was done in 2 wks, 4 wks total Drop outs: 0 | Outcomes: Pain: NRS, improvement of clinical signs as well as curative effect (scores in summary) Results: Immediate post tx: Pain: see summary Short term: NR Intermediate: NR Long term: NA | Outcomes: QoL/ well being: NR Results: Immediate post tx: Short term: NR Intermediate: NR Long term: NA Harms: NR Summary: the NRS scores decreased in three gps after 3 mo tx, especially CG (combination), t = 8.52, p < 0.01; most of the painful symptoms were controlled after 6 mo in CG (t = 7.08, p < 0.01)
Li, Q (1997)65 Country: China Quality score: 2/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: varied with pts. Final assessments: immediately post tx N screened: not mentioned N randomized: 156 N completed tx: 156 N attended last fu: NR Eligibility criteria:; - inclusion: NR; - exclusion: NR | Mean age (SD/range): NR % of male: IG, CG = 51.3% Racial composition: Asian Work status: NR Other socio-demographics: Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc/joint disease Duration of Pain: Acute, subacute, chronic, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 78) – Acu+cupping: major acupoints: shenshu, yaoshu, weizhong, renzhong, chize, supplement acupoint: for Pts with cold dampness , add yangguan, shangliao, xialiao; for pts with blood staganant, add geshu, and ganshu for pts with kidney debility, add mingmen, taixi retention 20 min+cupping: cupping on the shenshu, yaoshu and most painful point. retention 15 min; Acu: 1tx/d, 10 tx/course until cured; cupping:1tx/2ds Drop outs: B=0 CG (n = 78)– Acu: same as IG; 2tx/d, 10tx/course until cured Drop outs: B=0 | Outcomes: Pain: NA Disability: NA Results: Baseline: NA Pain: NA Immediate post tx: NA Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: well being Results: Immediate post tx: IG = 100%, CG = 97.4% improved Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: Acupuncture + cupping are significantly better than acu alone.
Liang, SY (2008)66 (abstract) Country: China Quality score: NA Initial of reviewer: SG | Trial Design RCT Tx duration: possibly 2 wks Final assessments: immediately post tx N screened: 112 N randomized: 112 N completed tx: NR N attended last fu: NR Inclusion: pts with myofacitis LBP Exclusion: NR | Mean age (SD/range): NR % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: myofacitis Duration of Pain: cannot tell Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 56) – Tendon muscle picking: picking pain tendon-muscle tubereles on the back; 2 tx courses(possibly 5 or 7 ds each), 14 sessions total Drop outs: NR CG (n = 56) – E-acu: at acupoints: BL 11; BL 13, BL 15, SI 11, and EX-B2; same as IG Drop outs: NR | Outcome instruments: Pain: NA Disability: NA Results: NA Baseline: NR Pain:NR Disabilty: Immediate post tx: Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Therapeutic effects (pain, work, and function): IG = 89.3% vs. CG = 78.6%, P < 0.05 Results: Baseline: NR Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR
Luo, S (2007)67 Country: China Quality score: /13 Initial of reviewer: SG | Trial Design RCT Tx duration: NR Final assessments: immediately post tx N screened: NR N randomized: 108 N completed tx: NR N attended last fu: NR Inclusion: varying degrees of LBP radiating to the lower limb. With straightened leg raising test, the raising </= 30 degrees in 37 cases, 31 - 65 in 68 cases, sand 3 cases with positive response in the intensive test. All pts diagnosed with CT and or MRI exam. Exclusion: NR | Mean age (SD/range): NR range 23-72 yrs % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: NR, 100% with radiating pain Duration of Pain: mixed, NR 1 d-17 yrs Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 56) – Scalp Acu + traction: STD scalp-point lines inserted by sterilized needles-pushed to the sub layer of galea aponeurotica. Needles manipulated when sucking sensation felt under the needle by Zhu’s reducing method; 5-8 min of needle retention, followed by qi method, needles retained for 30 min + traction Drop outs: NR CG (n = 52) – Traction: horizontal traction in supine position for mild pts and in prone position of severe cases; 30 min/session Drop outs: NR | Outcome instruments: Pain: NA Disability: NA Results: Baseline: Pain: NA Disability: NA Immediate post tx: Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Other: n (%) Clinically cured; marked effective’ improved; no change Results: Baseline: NR Immediate post tx: IG = 12 (21.4), CG = 7 (13.5); IG = 22 (39.3),CG = 18 (34.6); IG = 18 (32.1), CG = 16 (30.8); IG = 4 (7.1), CG = 11 (21.2) Short term: NR Intermediate: NR Long term: NR Harms: NR
Mu, JP (2007)63 Country: China Quality score: 5/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 3 wks Final assessments: immediately post tx N screened: NR N randomized: 120 N completed tx: 120 N attended last fu: NR Eligibility criteria:; - inclusion: lumbar herniation; age between 20-65; acute LBP less than 2 wks after lumber herniation diagnosed; not undergoing homonotherapy or taking steriod hormones; signed consent form; - exclusion: pregnant and postnatal woman; cardio-cerebrovascular disease; dropped off or cannot be followed up; lumbar tuberculosis and lumbar spinal cord tumor; | Mean age (SD/range): IG1 = 39 (8.7) yrs; IG2 = 37 (4.8) yrs; CG = 42 (6.5) yrs % of male: NR Racial composition:NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: 1-disc/joint disease Duration of Pain: Unknown: IG1 = 1.9 (1.7) yrs; IG2 = 2.1 (1.5) yrs; CG = 2.2 (1.9) yrs Severity of pain (Grading): NR Co-interventions: NR | Groups IG1 (n = 40)– E-acu-Jiaji points: Needle 75-90mm deep at EX-B2, connect needles with G805 electric impluse device, stimulate at freq. of 10-20Hz for 30min.; 1 sess/d x 21 sessions Drop outs: 0 IG2 (n = 40) – Laser needle knife grp: cut inter/supra spinal ligments and muscles. SJ-L laser needle-kinfe were remained for 30min; 1 session/wk for 3 wks CG (n = 40) – Jiaji EA + laser needle knife: Combine txs 1 and 2 Drop outs: | Outcome instruments: Pain: SF-MPQ Disability: NR Results: Baseline: Pain: 41.9 (2.0) vs. 42.4 (1.2) vs. 41.3 (1.8) Disability: NR Immediate post tx: Pain: 9.4 (1.8) vs. 8.5 (2.2) vs. 4.7 (1.3) Disability: NR Short term: Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Results: Immediate post tx: Cure rate: 25% vs. 35.1 vs. 47.4% effective: 47.5% vs. 46 vs. 44.7% ineffective: 27.5% vs. 18.9 vs. 7.9% total efficacy: 72.5% vs. 81.1 vs. 92.1% reoccurrence (6 mos post tx): 63% vs. 74.2 vs. 55.2% Short term: NR Intermediate: NR Long term: NHA Harms: NR
Peng, Y (2006)68 Country: China Quality score: 3/13 Initial of reviewer: SG | Trial Design-RCT- Tx duration: 20 ds Final assessments: immediately post tx N screened: unknown N randomized: 116 N completed tx: 116 N attended last fu: NR Inclusion: diagnosed using Chinese Medical Diagnostic and Therapeutic Standard 30-60 yrs CT-MRI examined and diagnosed and signed consent form Exclusion: pts with heart, brain blood vessel, liver, kidney or hemopoietic system disease, mental health, severe infection, pregnant women, lumbar vertebra tubercle, marrow tumor, and spondylolysis, prolapse in the middle with marrow disfunction, relapse after surgery those pts who dropped out and stransverse oscillatory rotped the tx were not included. | Mean age (SD/range): IG = 48 (10.61) vs. CG = 46 (11.3) yrs % of male: IG = 55.2%, CG = 51.7% Racial composition: Asian Work status: NR Other socio-demographics: Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc/joint disease Duration of Pain: NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 58) – round sharp needle+massage: major acupoints: tuxue (pain point beside lumbar vertebra s pinous process), supplement acupoints: with pain in zutaiyangjing, add zhibian, yinmen, chengshan, weizhong, kunlun; with pain in zushaoyangjing, add huantiao, fengshi, xuanzhong, zusanli, yanglingquan, qiulinquan, qiuxu, kunlun; with pain in both, press taiyangjing, zushaoyangjing; with qi stagnant, add yaoyangguan, xuehai; with colddampness, add sanyinjiao, minmen, liver or kidney deficit, add ganshu and shenshu. 0.15mm x87 mm round sharp needle for major points 0.30 mmx40 mm filiform needle retention 30 min massage: rolling manipulation on waist and buttock for 10 min, massage on muscle beside lumbar vertebra, then knock the same spots lightly. Then let the Pt sleep on his/her side, massage Pt's shoulder, then relax for 5 min.; 1tx/d, 10tx/course, rest 2 ds, 2 courses Drop outs: unknown CG (n = 58)– filiform needle + massage: acupoints are all the same as those in the tx group, just use filiform needle; same as IG Drop outs: unknown | Outcomes: Pain: NA Disability: NA Results: Baseline: NA Pain: NA Immediate post tx: NA Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: well being, B, Chinese Medical Diagnostic and Therapeutic Standard Results: Immediate post tx: IG = 98.3%, CG = 82.8% improved (P<0.01) Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: round sharp needle combined with massage has a better therapeutic effect on prolapse of lumbar intervertebral disk.
Qian-mei (2007) 69 Country: China Quality score: 4/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 7 wks Final assessments: imm. post-tx N screened: NR N randomized: 116 N completed tx: 116 N attended last fu: 116 Eligibility criteria:; - inclusion: diagonosed as lumbar herniation according to “traditional Chinese medicine diagnostic efficacy standards”; - exclusion: age >70; undergoing other therapies and taking steriod hormones; Cauda equina syndrome; pregnant and postnatal woman; card io-cerebrovascular disease | Mean age (SD/range): NR % of male: IG = 51.5% Vs. CG = 56% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc/joint disease Duration of Pain: acute; subacute (up to 12 wks); Chronic (> 12 wks), NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 66)– Needling acupoints at same nervous segment: insert needles 60mm deep, stimulate manually until soreness and numbness reached, PM such as light nd heat applied on low back; 3 sess/wk x 21 sess. Drop outs: A= 0 CG (n = 50) – Needles were inserted at routinely selected acupoints on low back and buttock; same as IG Drop outs: A= 0 | Outcome instruments: Pain: NA Disability: NA Results: Baseline: Pain: NA Disability: NA Immediate post tx: Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Other: cure rate; efficacy rate Results: Immediate post tx: Cure rate: 37% vs. 13% significantly effective: 23% vs. 20% ineffective: 1% vs. 7% total efficacy: 90.9% vs. 66% Short term: NR Intermediate: NR Long term: NR Harms: NR
Qu, Y (2006)70 Country: China Quality score: 2/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 1 wk Final assessments: immediately post tx N screened: 120 N randomized: 120 N completed tx: NR N attended last fu: NR Inclusion: outPts with dx on syndrome of L3 transverse process (in Criteria on Diagnosis and Theraputic Effects on Syndromes of Chinese Medicine) randomized based on visiting sequence (results separated for acute to subacute and chronic pts) Exclusion: NR | Mean age (SD/range): IG - range 25 – 61, CG - 23 - 65 yrs % of male: IG = 58%, CG = 55% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: syndrome of L3 transverse process % NS: % S: Duration of Pain:mixed, IG - (31 chronic, 29 actue - subacute), CG - (33 chronic, 27 acute - subacute) Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 60)– Acu with warming needles: subcutaneous injection with 0.5% lidocaine done on punctured points with pimple formed about 5 mm in diameter, during the moxibustion, if the skin burning on the acu spot was hardly tolerated the aseptic physiological saline was sparyed Drop outs: NR CG (n = ) – E-acu: bilateral application with filiform needle (0.30 mm x 50 mm); even needling technique, electric acu apparatus was applied with continuous wave, 50 hz , 2 - 4 V. needles were retained for 30 min; , 1tx/d, 7 tx total Drop outs: NR | Outcome instruments: Pain: NA Disability: NA Results: Baseline: NA Pain: Disability: Immediate post tx: NA Pain: Disability: Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Therapeutic effects: Cured; Improved; No effect; Total n (%) Results: Immediate post tx: IG = 49 (81.7), CG = 35 (58.3); IG = 10 (16.7), CG = 22 (36.7); IG = 1 (1.6), CG = 3 (5); IG = 59 (98.4), CG = 57 (95) Short term: NR Intermediate: NR Long term: NR Harms: NR
Rui-ping She (2008)71 Country: China Quality score: 3/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 20 ds Final assessments: immediately post tx N screened: NR N randomized: 179 N completed tx: 179 N attended last fu: NR Inclusion: show 7/10 following symptoms LBP; sciatica; lower limb numbness; limp intermittently; protective posture; Deformity of spinal cord; straight leg raise test (+); Bragard's test (+); dysuria or lower limb myophagism; CT: dura mater and nerve root disturbed; MRI: intervertebral space narrow Exclusion: spondylolisthesis; myofacial pain syndrome; spinal canal stenosis or spinal fracture; | Mean age (SD/range): NR % of male: IG = 55%; CG = 56.8% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: 1 - disc/joint disease Duration of Pain: acute; subacute (up to 12 wks); Chronic (> 12 wks); NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: 1.lay on solid bed for 16hrs 2.waist and back support | Groups IG (n = 140)– Acu at Qiangji 4 points deeply insert needles until vertebrae reached connected to impulse device and stimulated at tolerated freq.; 40 min/sess, 1 sess/d x 20 ds, 5 ds break after 10 sessions Drop outs: NR CG (n = 139) – Routine acu: needles were inserted 25-40mm deep, manipulate needles connected with electrical impulse device and stimulated at tolerated frq.; same as IG Drop outs: NR | Outcomes: Pain: NR Disability: NR Results-Baseline: Pain: NR Disability: NR Immediate post tx: Pain: NR Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Other: cure rate Results: Cure rate: End of 1^st^ course: 42.1% vs. 28.1% End of 2^nd^ course: 82.9% vs. 16.8% Intermediate: Long term: NR Harms: NR Summary:
Wang, Y (2004)72 Country: China Quality score: 2/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: NR Final assessments: immediately post tx N screened: not mentioned N randomized: 111 N completed tx: 111 N attended last fu: NR Eligibility criteria:; - inclusion: diagnosed third lumbar vertebra transverse process syndrome; - exclusion: NR | Mean age (SD/range): NR % of male: IG = 68.2% vs. CG = 60% Racial composition: NR (most likely Asian) Work status: NR Other socio-demographics: Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 66) – Waiguan-through-Neiguan and Lumbus 2-4 , transverse process acu methods: 40-50 mm needle on waiguan-through-Neiguan 75 mm needle on lumbus 2-4 retention 30 min; 1tx/d, 10 tx/course Drop outs: B=0 CG (n = 45)– routine acu: acupoints: shenshu, zhishi, zhibian, weizhong eletronic acu retention 30 min; same as IG Drop outs: B=0 | Outcomes: Pain: NA Disability: NA Results: Baseline: NA Pain: NA Immediate post tx: NA Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: Well being, B Results: Immediate post tx: IG = 95.5%, CG =71.1% improved (P<0.05) Short term: NR Intermediate: NR Long term: NR Harms: NR Summary (if provided) : IG = cure rate and total effective rate were 66.7% and 95.5%, CG = 46.7% and 71.1% respectively, showing that the curative effect was better in the IG than in the CG
Wang, YQ (2005)73 Country: China Quality score: 6/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 20 ds Final assessments: NR N screened: 58 N randomized: 58 N completed tx: 58 N attended last fu: NR Eligibility criteria:; - inclusion: disc herniation; - exclusion: Obvious symptoms in Pts with spinal cord compression | Mean age: 45.7 yrs % of male: IG = 76.7% vs. CG = 71.4% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc herniation Duration of Pain: Unknown or mixed duration, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 30)– Acu + massage+ spinal Mob: Ventral acu; 32# needle, 50min/d x 2 courses each 10 ds Drop outs: 0 CG (n = 28) – massage + spinal Mob: NR; 20 min/d x 2 courses, 10 ds each Drop outs: 0 | Outcome instruments: Pain: VAS(A, B); Overall efficiency (B) Disability: NA Results: Immediate post tx: Pain: IG = 0.83 (0.23), CG = 2.85 (0.49); Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Overall efficacy Other: NA Results: Immediate post tx: overall efficacy: 64% vs. 85%, p < 0.05 Short term: NR Intermediate: NR Long term: NR Harms: NR Summary of results (if provided): massage plus spinal Mob plus acu group is better than massage plus spinal Mob group
Wu, Y (2004)74 Country: China Quality score: 3/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: 30 ds Final assessments: immediately post tx N screened: not mentioned N randomized: 114 N completed tx: 114 N attended last fu: NR Eligibility criteria:; - inclusion: diagnosed using Chinese Medical Diagnostic and Therapeutic Standard; - exclusion: NR | Mean age (SD/range): NR % of male: IG = 62.9% vs. CG = 57.7% Racial composition: Asian Work status: NR Other socio-demographics: Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc/joint disease Duration of Pain: Acute, subacute, chronic Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 62) –Abdominal acu: acupoint: 40-60 mm needle; 1 tx/d, 10tx/course, 3 ds between courses x 3 courses Drop outs: B=0 CG (n = 52)– Body acu:, retention for 30-50 min; same as IG Drop outs: B=0 | Outcomes: Pain: NA Disability: NA Results: Baseline: NA Pain: NA Immediate post tx: NA Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: well being, Results: Immediate post tx: IG = 98.4%, CG = 86.5% improved (P<0.025) Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: abdominal acu has a good therapeutic effect on prolapse of lumbar intervertebral disc with a short therapeutic course
Xia, F (1997)75 Country: China Quality score: 2/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: 1 mo Final assessments: immediately post tx N screened: not mentioned N randomized: 81 N completed tx: 81 N attended last fu: NR Eligibility criteria:; - inclusion: Xray or CT diagnosed; - exclusion: NR | Mean age (SD/range): NR % of male: NR Racial composition: Asian Work status: NR Other socio-demographics: Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc/joint disease Duration of Pain: Acute, subacute and chronic Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 41) – Acu+injection+massage: acupoint: jiaji, add huantiao, fengshi, yanglingquan, juegu, ashixue for lumbar or leg pain on zushao yangdan jing; add zhibian, yinmen, weizhong, chengshan, kunlun, aishixue for pain on taiyang pangguangjing. Retention 15 min, every 5 min run needle once injection: B1, B12 4 ml injection into 3-4 acupoints massage waist and leg (affected sides), shake ankles; 1tx/2ds, 10 tx/course, 5 ds rest Drop outs: B=0 CG (n = 40)– Acu: acupoint: jiaji, add huantiao, fengshi, yanglingquan, juegu, ashixue for lumbar or leg pain on zushao yangdan jing; add zhibian, yinmen, weizhong, chengshan, kunlun, aishixue for pain on taiyang pangguangjing. Retention 15 min, every 5 min run needle once; same as IG Drop outs: B=0 | Outcomes: Pain: NA Disability: NA Results: Baseline: NA Pain: NA Immediate post tx: NA Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: well being, B Results: Immediate post tx: IG = 98%, CG = 90% improved (P<0.05) Short term: NR Intermediate: NR Long term: NR Harms: NR
Xingsheng, C (1998)76 Country: China Quality score: 2/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 10-30 ds Final assessments: immediately post tx N screened: NR N randomized: 198 N completed tx: NR N attended last fu: NR Inclusion: Pts with sciatica aged ≥ 18 yrs Exclusion: Pts with fractures or visceral referred pain from infection, neoplasm, or aortic aneurysm | Mean age : 45.6 yrs % of male: 59.1% Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: sciatic neuritis; lumbar hyperosteogeny; prolapsed intervertebral disc; soft tissue injury; sacroilitis; coxarthritis; sciatic nerve injury by injection: rheumatoid spondylitis; lumbarization of sacrum; Duration of Pain: Mixed, 3.5 mos (2d-12 yrs) Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 108)– Acu(PTP+DP): Point-To-Point Penetration method + Deep Puncture; manual twirling was used to obtain local sensations of soreness and distenstion; the needle retained for 30 min; 1-2 tx/d, 10 sessions/course, 1-3 courses Drop outs: NR CG (n = 90) – Acu(routine): Routine filiform needling techniques; points chosen according to individual manifestations; manual twirling as IG Drop outs: NR | Outcome instruments: Pain: NR Disability: NR Results: Baseline: NA Pain: Disability: Immediate post tx: NA Pain: Disability: Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Other: Cured: all signs and symptoms disappeared completely and affected limb moved freely Results: Short term: NR Intermediate: IG = 74 (68.5%), CG = 31 (34.4%) Long term: NR Harms: NR
Yao, Z (2007)77 Country: China Quality score: 3/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 21 ds Final assessments: immediately post tx N screened: Don’t know N randomized: 116 N completed tx: 116 N attended last fu: NR Eligibility criteria:; - inclusion: diagnosed using Chinese Medical Diagnostic and therapeutic Effective Standard,; - exclusion: fracture, tumor | Mean age (SD/range): NR % of male: NR Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc/joint disease Duration of Pain: less than 2 mons to greater than 6 mons, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 62)– Acu + moxibusion: Acupoint: Huatuo Jiaji xue, 30 min retention, TDP moxibusion , select 4, 5, 6 point in the lower limb of the affected side, 40 mm needles, 40 min retention; 1 tx/d, 6 tx/course, 1 d between courses x 3 courses Drop outs: B=0 CG (n = 54) – E-acu-acupoints: shenshu, dachangshu, guanyuanshu, huantiao, fengshi, weizhong, fenglong, zhusanli, jugu, kunlun, taichong. 30 min retention; same as IG Drop outs: B=0 | Outcome instruments: Pain: NA Disability: NA Results: Baseline: NA Pain: Disability: Immediate post tx: NA Pain: Disability: Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: well being, B: pain and symptoms disappear, waist function is back to normal, can return to work Other: Results: Immediate post tx: IG = 91.9%, CG = 90.7% improved (P>0.05) Short term: NR Intermediate: NR Long term: NR Harms: N
Ye, D (2002)78 Country: China Quality score: 2/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 2 mos Final assessments: immediately post tx N screened: not mentioned N randomized: 60 N completed tx: NR N attended last fu: NR Eligibility criteria:; - inclusion: 1-diagnosed using Chinese Medical Diagnostic and therapeutic Standard; - exclusion: NR | Mean age (SD/range): NR % of male: NR Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc/joint disease Duration of Pain: acute, subacute and chronic, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG1 (n = 20)– eletric acu+traction+Tuina(mas sage: acute-pelvis traction for 20 min then electric acu, Retention 15 min(5Hz-10Hz)+20min (0.5Hz-1 Hz); 1 tx/d, 10 tx/course x 3, subacute and chronic period-electric acu and traction (same as IG1),+ Tuina 20 min, 1 tx/2 ds, 10 tx/course, 3 courses Drop outs: don’t know IG2 (n = 20) – electric acu+traction: tx of electric acu and traction as IG1; same as IG1 Drop outs: don’t know CG (n = 20) – electric acu+Tuina(massage: tx of eletric acu and Tuina as IG1; same as IG1 Drop outs: Don’t know | Outcome instruments: Pain: NA Disability: NA Results: Baseline: NA Pain: Disability: Immediate post tx: NA Pain: Disability: Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: well being, B, Chinese Medical Diagnostic and therapeutic Standard Results: Immediate post tx: improved IG = 95%, IG2 = 90%, CG = 90% Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: electric acu + traction mainly applied for the early stage and Tuina combined by electric acu + traction for the middle-later stage
Ye, L (2004)79 Country: China Quality score: /13 Initial of reviewer: SG | Trial Design RCT- Tx duration: 3 wks Final assessments: immed. Post-tx N screened: NR N randomized: 98 N completed tx: 98 N attended last fu: 98 Inclusion: MRI and CT examination, using Chinese Medical Diagnostic and Therapeutic Standard for lumbar intervertebral disc Exclusion: NR | Mean age (SD/range): IG = 38.3(possibly total) % of male: 51 %(assuming total) Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Prolapse of lumbar intervertebral disc Duration of Pain: mixed, 369.4, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 49) – hypodermic catgut embedding therapy on prolapsed of lumbar intervertebral disc, acupoints: jiaji, huantiao, weizhong, xuanzhong, ashi. 3-5cm beside acupoints, embeded 3-4cm hypodermic catgut; 1 tx/course, embedded for a wk then for next course, 3 courses total Drop outs: B = 0 CG (n = 49) – E-Acu: NR; NR Drop outs: NR | Outcomes: Pain: score (put under pain tab, however it is a score for symptoms somatoscopy and activity of daily life), A, B Results: Baseline: Pain: IG = 9.49 (1.29), CG = 9.47 (1.32) Immediate post tx: Pain: IG = 18.31 (1.83), CG = 15.54 (1.92) Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: Well-being, B, Other: Results: Immediate post tx: % improved: IG = 44, P = 0.897959184; CG = 42, P= 0.857142857 Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: The hypodermic satgut embedding therapy can increase therapeutic effect on prolapse of lumbar intervertebral disc
Ye, Z (2004)80 Country: China Quality score: 2/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 20 – 60 ds Final assessments: immediately post tx N screened: Don’t know N randomized: 56 N completed tx: 56 N attended last fu: NR Eligibility criteria: inclusion: Diagnostic as lumbar intervertebral disc protruston using CT examination and based on Shanghai Chinese Medical Diagnostic and Treatment Standard exclusion: NR | Mean age (SD/range): IG = 45 vs. CG = 44 yrs % of male: IG = 76.7%, CG = 76.9% Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc/joint disease Duration of Pain: IG - 1 wk to 12 mo : acute to chronic; CG - 5 ds to 11 mo: acute to chronic Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 30)– Needle-knife +Take Chinese medicine + therapy by hand: 50-100kg traction, after 15 min, local anesthesia, use needle-knife; therapy by hand +Chinese Medicine; 6 tx total, 5 ds between 2 tx Drop outs: 0 CG (n = 26) – Eletroacu +Take Chinese medicine+ herapy by hand; 1 tx/d, 10 tx/course, 3-5 d no tx between course, total of 6 course Drop outs: 0 | Outcome instruments: Pain: NR Disability: NR Results: Baseline: NA Pain: Disability: Immediate post tx: NA Pain: Disability: Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Cure rate Results: Immediate post tx: improved; overall: IG = 100%, CG = 88.5 %, P<0.05 Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: Needle-knife composite tx is superior to electro-acu composite tx.
Zeng, Y (2007)81 Country: China Quality score: 2/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: NR Final assessments: immediately post tx N screened: NR N randomized: 133 N completed tx: 133 N attended last fu: NR Inclusion: diagnosed using Chinese Medical Diagnostic and therapeutic Effective Standard; 20-65 yrs; CT or MRI exam showed lumbar intervertebral Disc Protrusion; Signed consent form Exclusion: disease with heart, brain vessel, liver, kidney and blood producing problem, mental health; infection, pregnant women, women in breast feeding, lumbar spinal tubercal, spinal cord tumor, dysfunction with spinal cord, relapse after surgery | Mean age (SD/range): NR % of male: IG = 44.8% vs. CG = 48.5% Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc/joint disease Duration of Pain: acute, subacute, chronic, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 67)–Abdomen acu: acupoint: shuifen, qihai, guanyuan, renzhong+yintang for acute lumbar intervertebral disc protrusion, Qixue (two sides) +siman (two sides) +wailin (two sides) for waist pain, qipang (healthy side)+wailin (healthy side) for sciatic nerve pain+ lower rheumatism point (affected side) retention 30min; 1 tx/d, 10 tx/course Drop outs: B =0 CG (n = 66) –Body acu: acupoint: dachangshu, guanyuanshu, baliao, jiaji, chibian, huantiao, chengshan, yinmen, weizhong, yanglingquan, fengshi, kunlun. Points on affected side retention 30 min; same as IG Drop outs: B =0 | Outcome instruments: Pain: NA Disability: NA Results: Baseline: NA Pain: NA Disability: NA Immediate post tx: NA Pain: NA Disability: Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: well being, B, based on Chinese Medical Diagnostic and therapeutic Effective Standard Results: Immediate post tx: IG = 95.5%, CG = 86.4% improved Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: abdomen acu has a good effect on lumbar intervertebral disc protrusion with a short course of tx
Zhang, B (2002)82 Country: China Quality score: 2/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: not clear Final assessments: immediately post tx N screened: Don’t know N randomized: 278 N completed tx: NR N attended last fu: NR Inclusion: Diagnosed using X-ray and CT examination and Clinical Disease Diagnostic and therapeutic Effective-Chinese ref 1987 Exclusion: Tumor, facture, inflammation in lumbar spine, internal organ failure, tubercle in lumbar spine | Mean age: IG1 = 46, IG2 = 43, CG = 47 yrs % of male: IG1 = 69.8%, IG2 = 60.7%, CG = 66.3% Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: disc/joint disease Duration of Pain: 3 ds-10 yrs: acute, sub-acute, chronic Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 96)– Acu+ massage: on S acup points; 1 tx/d, 10tx/course, 3-5 d between tx Drop outs: B = 0 IG2 (n = 84) – Acu: same as IG1; 2 tx/d, 10 tx/course, 3-5 ds between tx Drop outs: B = 0 CG (n = 98) – Massage: lay on tummy, rolling, rubbing massage on waist and lower limb, manipulation on huatuojiaji and beishu for 10 min, traction for 1 min, and repeat 3-5 times, stretch and shake waist and left and right turn for 2-3 times, Roll, rub and push from waist to two lower limbs for 5 mins followed by 1 hour rest 3 tx/d, 10 tx/course, 3-5 ds between tx Drop outs: B = 0 | Outcome instruments: Pain: NR Disability: NR Results: NR Immediate post tx: Pain: Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: Cure rate Results: Immediate post tx: N (%) improved – IG1 = 96 (100%), IG2 = 73 (86.9%), CG = 90 (91.8%) Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: IG1 is superior to IG2 or CG tx and at present is one of the better methods for treating lumbar intervertebral disc protrusion
Zhang, B (2007)83 Country: China Quality score: 6/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 20 ds Final assessments: immediately post tx N screened: NR N randomized: 194 N completed tx:188 N attended last fu: NR Eligibility criteria:; - inclusion: Pts aged 25-60 yrs with LDH not taking any therapies; - exclusion: LDH cases with complications of lumbar spondylolisthesis; complications of general collagenous immune diseases or other infections; those taking glucocorticoids or with severe complications | Mean age (SD/range): IG = 47.6 (5.23) vs. CG = 46.9 (6.12) yrs % of male: IG = 50%, CG = 50% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: NR Duration of Pain: Acute-chronic: IG – 1 mo-10yrs; CG – 3wks-20yrs Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 98) – E-Acu: filiform 0.38 mm diameter needles of 40-70 mm length inserted 1.5-2 cun, followed by 2 min reinforcing and reducing manipulations by rotating until electric shock sensation; afterwards, the needles were connected to G6805-II electric stimulator for 20 min with continuous wave 40 HZ frequency and 2mA intensity; 1tx/d, 10d/course for 20 d, 5 d between 2 courses Drop outs: 2 CG (n = 96) – Mobic: NR; 7.5 mg/d orally for 20 d (2 Tx courses each 10 d and 5 d apart) Drop outs: 4 | Outcome instruments: Pain: Shanghai Diagnose and Treatment Routine of TCM Syndromes issued by Shanghai Municipal Health Bureau; Scoring of pain: not obvious=0, occasional/mild=1, occasional severe or frequent mild=2, frequent severe=3 Disability: Results: Baseline: Pain: NR Disability: NA Immediate post tx: Pain: NR Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Other: N of pts with >50% pain reduction: IG = 82%, CG = 73% Results: Baseline: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR Summary of results (if provided): E-Acu was more effective than Western drug in improving LBP, pain in lower limbs, walking, sensory function, SLR and muscle power
Zhang, BM (2008)84 Country: China Quality score: 4/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 20 ds Final assessments: immediately post tx N screened: 200 N randomized: 200 N completed tx:196 N attended last fu: NR Inclusion: Disc herniation; 25-60yrs; Eexclusion: Disc herniation with spondylolysis; Pts oral glucocorticoid | Mean age (SD/range): IG = 47.62 (5.23) Vs. CG = 46.96 (6.12) yrs % of male: IG = 53.1 %; CG = 51 % Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc Herniation Duration of Pain: IG - Acute (< 4 wks) ; CG - Chronic (>/= 12 wks) Severity of pain (Grading): NR Co-interventions: No description; IG = 3.06, CG = 56.25 | Groups IG (n = 100)– E-acu with current intensity of 2 mA at frequency of ; 4HZ; 20min/once a d for 10 ds with 5 ds interval Drop outs: A = 1, B = 1 CG (n = 100) – Oral Med: 30# 1.5 and 3 inch needle; MOBAC tablets 7.5 mg/d x 10 d/course x 2 Drop outs: A = 1, B =1 | Outcomes: Pain: NR Disability: NR Results: Baseline: Pain: NR Disability: IG (n = 96), CG (n = 91); IG (n = 85), CG (n = 80); IG (n = 80, CG (n = 84); IG (n= 82), CG (n = 88); IG (n = 72), CG (n= 74) Immediate post tx: Pain: NR Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: overall efficacy Results: Immediate post tx: overall efficacy (%): 86.53% vs. 75%, p < 0.01 Short term: NR Intermediate: NR Long term: NR Harms: poor appetite, nausea, abdomen pain, swelling, headache and dizziness in CG but not in IG – Local hematoma 3.06% in IG Summary of results: e-acu is better than oral medicine in improving lumbago, pain or numbness of lower limb, walking ability , raising straight leg and muscle stretngh
Zhang, Honglai (2003)85 Country: China Quality score: 6/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 45 ds Final assessments: immediately post tx N screened: unknown N randomized: 120 N completed tx: 120 N attended last fu: NR Inclusion: diagnosed as Cervical Spondylosis using ref [1] 1993-chinese, Special attention (only those who were compliant with the tx, only those who responded to the surveys) Exclusion: acute external injury cause, not compliant | Mean age (SD/range): NR % of male: IG = 53.3%, CG = 55% Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Spondylosis Duration of Pain: Chronic, IG = 81.9 mo, IG2 = 92.2 mo, CG = 91.1 mo Severity of pain (Grading): McGill, VAS Co-interventions: NR | Groups IG (n = 60)– Electro-acu: tianzhu, jinbailao and dashu (two sides) for major acu points dazhui, fengchi, fengmen, jianjin and waiguan for wind dampness quchi, pishu, fenglong, geshu for tanyuzhu type ganshu, pishu, and zusanli for qi stagnant type ganshu, pishu, zusanli for qi and blood stagnant type yanglao, ganshu, shenshu and taixi for liver and kidney debility. 1.5 Chinese inch, size 30 needle, freq. 120-250/min, retention 30min; 1 tx/d, 15 tx/course, 3 courses, 2 d rest between courses Drop outs: A = NR, B= 0 CG (n = 60) – Traction: 30 min, average traction = 7.5kg; Same as IG Drop outs: A = NR, B= 0 | Outcomes: Pain: McGill PRI total; difference between baseline and fu on VAS Results: Baseline: Pain: IG = 8.57 (2.33), CG = 8.61 (2.42); NR Immediate post tx: Pain: IG = 6.73 (2.12), CG = 7.55 (2.28); IG = 4.87 (1.67), CG = 3.56 (1.26) Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Cure, improved, effective, no effect n (%) Results: Immediate post tx: IG = 56 (93.3%), CG = 47 (78.3%) Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: IG in therapeutic effect and improvement of pain for cervical spondylosis is better than the CG. This study found that both tx have better effect with younger pts compared with older pts
Zhang, Zhong-yi (2002)86 Country: China Quality score: 1/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 10 wks Final assessments: immediately post tx N screened: Don’t know N randomized: 61 N completed tx: 61 N attended last fu: NR Eligibility criteria:; - inclusion: diagnosed as Lumbar Intervertebral Disc Protrusion using X-ray, CT or MRI; - exclusion: NR | Mean age (SD/range): NR % of male: NR Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc/joint disease Duration of Pain: IG and CG -5d to 18 yrs: acute, subacute and chronic, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 30)– Acu+ massage: acupoints: qihaishu, dachangshu, guanyuanshu, xiaochangshu, huatuojiaji supplement acupoints: zhibian, huantiao, xiajuliao, chengfu, weizhong, yanglingquan, chengshan and kunlun 50mm diameter, 75-100 mm needle retention 20min and cupping on affected sides for 20 min; 2 tx/wk, 10 tx/course x 2 Drop outs: NR CG (n = 31) – Massage: massage on the affected side, pressure the pain point, huantiao, chenfuxue. Then massage weizhong, chenshang, kunlun, taixi, xiexi; same as IG Drop outs: B = 0 | Outcome instruments: Pain: NR Disability: NR Results: Baseline: NA Pain: NA Disability: NA Immediate post tx: NA Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: well being, B, based on Chinese Medical Diagnostic and therapeutic Effective Standard 1994 Results: Immediate post tx: Improved: IG = 96.7%, CG = 90.3% Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: The curative effect is better in the IG than in the CG.
Zhong, B (2006)87 Country: China Quality score: 2/13 Initial of reviewer: SG | Trial Design RCT Tx duration: NR Final assessments: immediately post tx N screened: NR N randomized: NR N completed tx: NR N attended last fu: NR Eligibility criteria:; - inclusion: Had injuries, caught cold; Waist pain accompanied with sciatic nerve pain; Lumbar bend, limitation on movement, pain around Jitu with radiating pain, skin nerve control too sensitive or obtuse,; - exclusion: <15 or >65 yrs | Mean age (SD/range): NR % of male: NR Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Lumber vertebra tranverse Duration of Pain: acute, subacute, chronic, N Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = NR)– Abdominal Acu + traction + body acu: abodominal acu: major point: shuifen, qihai, add guanyuan. Wailin, siman for waist pain, add qipang, wailing(affected side), lower ; NR Drop outs: CG (n = NR) – Lumbar traction + body acu: NR; NR Drop outs: NR | Outcome instruments: Pain: NA Disability: NA Results: NA Baseline: Pain: Disability: Immediate post tx: NA Pain: Disability: Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Total efficacy rate: Results: Immediate post tx: IG = 96.88%; CG = 89.29%, Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: Abdominal acu + traction and body Acu as acomposite tx has an exact effect on lumbar intervertebral disc protrusion
Zhou, Q (1998)88 Country: China Quality score: 3/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: 30 ds Final assessments: immediately post tx N screened: not mentioned N randomized: 58 N completed tx: 58 N attended last fu: NR Eligibility criteria:; - inclusion: CT diagnosed as lumbar interverbral disc protrusion; - exclusion: NR | Mean age (SD/range): IG and CG = 48 yrs % of male: NR Racial composition: Asian Work status: NR Other socio-demographics: Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc/joint disease Duration of Pain: 4 d to 4 yrs, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 30) –Acu on Jiaji: lumbar intervertebral disc protrusion to left or right, chose acupoints : huatuo jiaji (affected side), supplement acupoints: chibian, huantiao, yinmen, weizhong, chengshan, kunlun or fengshi, yanglinquan, juegu, qiuxu. Lumbar intervertebral disc protrusion to middle chose acupoints: huatuojaji (two sides), supplement acupoints as above. retention 20 min, + moxibusion on lumbar acupoints; 1 tx/d, 10tx/course x 3 courses Drop outs: B=0 CG (n = 28)– acu on pangguangjingxue: acupoints : pangguang (affected side, or two sides), e.g qihaishu, dachangshu, guanyuanshu, xiaochangshu. supplement acupoint as above; same as IG Drop outs: B=0 | Outcomes: Pain: NA Disability: NA Results: Baseline: NA Pain: NA Immediate post tx: NA Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: well being, B Results: Immediate post tx: IG = 90%, CG = 75% improved (P<0.05) Short term: NR Intermediate: NR Long term: NR Harms: NR
Zhou, Q (1998)89 Country: China Quality score: 4/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: NR Final assessments: immediately post tx N screened: not mentioned N randomized: 192 N completed tx: 192 N attended last fu: NR Eligibility criteria:; - inclusion: diagnosed using Chinese Medical Diagnostic and Therapeutic Standard and 1988 Clinical Trial Diagnostic Standard 20-65 yr; Signed consent form; - exclusion: pregnant, breast feeding women, Pts with heart or brain blood vessel, liver, kidney primary disease diagnosed as prolapse of lumbar intervertebral dic but no nerve root pain | Mean age: 45 yrs % of male: 51 Racial composition: Asian Work status: NR Other socio-demographics: Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc/joint disease Duration of Pain: NR, IG = 1.9 (1.7) yrs; CG1 = 2 (1.6)NS; CG2 = 1.9 (1.6)NS Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 96) – Huaisanzhen: acupoints: huaisanzhen, 0.35 mmx 75 mm needle, retention 30 min ; NR Drop outs: B=0 CG1 (n = 48) – Drug: injection of Bilinfen 0.9g+physiological saline 2 ml; NR Drop outs: B =0 CG2 (n = 48)– Acu: acupoint: shenshu, qihaishu, jiaji, ciliao, zhibian, huantiao, ashixue, weizhong, yanglinquan, xuanzhong retention 30 min; NR Drop outs: B=0 | Outcomes: Pain: pain, VAS, 1 hour later, 12 hours later, 24 hours later, 48 hours later Disability: NA Results: Baseline: Pain: IG = 10, CG1 = 10, CG2 = 10 Immediate post tx: Pain: IG = 3.7 (1.5), CG1 = 5.5 (2), CG2 = 5.2 (1.2) Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: Well being, Chinese Medical Diagnostic and Therapeutic Standard Results: Immediate post tx: IG = 83.3%, CG1 = 6.3%, CG2 = 8.3% improved Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: timing analgesic effect was shorter, the effect lasting time was longer, and the analgsic effect and the comprehensive therapeutic effect were better in the IG vs. CG1, &2 (P<0.01)
Zhou, YL (2006)90 Country: China Quality score: 5/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: 10 ds Final assessments: immediately post tx N screened: 380 N randomized: 310 N completed tx: 310 N attended last fu: NR Eligibility criteria:; - inclusion: Disc herniation; VAS ≥ 3; Sign a consent form; 20-65 yrs; - exclusion: NR | Mean age (SD/range): IG1 = 45.72 (11.2); IG2 = 44.44 (10.36); CG = 46.08 (10. 76) yrs % of male: IG1 = 51.9%; IG2 = 46.1% CG = 44.4% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc herniation; Degenerative disc disease Duration of Pain: Unknown or mixed duration, IG1 2.62 (2.55) yrs; IG2 = 2.58 (2.7) yrs; CG = 2.60 (2.57) yrs Severity of pain (Grading): NR Co-interventions: NR | Groups IG1 (n = 162) –Acu-ankle-three-needle: points Gentong NO.1, 2 and 3 were selected; needle:size 75mm, 30min Drop outs: 0 IG2 (n = 76) – Routine Acu: acu at Shenshu, Qihaishu,Jiaji and Qilao; needle:size 75mm, 30min Drop outs: 0 CG(n = 72) – Med inject: routine buttock intramuscular injection of aspirm-DL-lysine plus saline; aspirm-DL-lysine 0.9g plus saline 2ml Drop outs: 0 | Outcomes: Pain: VAS only at baseline; time of inducing analgesia Disability: NR Results: Immediate post tx: Pain: VAS-NR time of inducing alagesia, minutes: 6 vs. 27 vs. 18 minutes Effect lasting for 24.5 vs. 8.9 vs. 6.4 hours Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: Other: straight-leg raising test Results: Immediate post tx: IG1 = 61.7 (13.4); vs. 52.1 (18.9); vs. 53.6 (15.2) Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: Analgesic effect within 48 hrs, Straight leg raising test: ankle-three-needle group is better than the other two groups but there are not different between routine acu group and medicine injection group.
Zhou, Z (2004)91 Country: China Quality score: 4/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: 24 ds Final assessments: immediately post tx N screened: not mentioned N randomized: 160 N completed tx: 160 N attended last fu: NR Eligibility criteria:; - inclusion: 1-LBP or sciatic nerve pain, pain may become worse when coughing, sneezing or bow movement 2-pain on lumbar vertebra or sciatic nerve, test of rasing straight leg 3-CT or MRI exmination diagnostic lumbar intervertebral disc protrusion; - exclusion: spinal stenosis, tumor | Mean age (SD/range): NR % of male: IG = 66.7% vs. CG = 60% Racial composition: Asian Work status: NR Other socio-demographics: Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc/joint disease Duration of Pain: acute, subacute, chronic Severity of pain (Grading): NR Co-interventions: TDP illuminate abdomen (around shenque ) + 250 ml Danshen injection | Groups IG (n = 42) – Abdominal acu + Danshen injection+ light illuminate: (for short acute, use shallow acu; long acute, use deep acu); 30 min retention 250 ml Danshen injection; 1 tx/d, 6tx/course x 4 courses, 1 d rest between courses, injection: 1 tx/d for 20 ds Drop outs: B =0 CG (n = 40)– Lumbar shallow acu +Danshen injection+ TDP illuminate: use shallow lumbar acu, acupoint in lumbar and leg . TDP illuminate lumbar area (L4-5 as centre), 30 min retention 250 Danshen injection Drop outs: B =0 | Outcomes: Pain: NA Disability: NA Results: Baseline: NA Pain: NA Immediate post tx: NA Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: well being, B, Chinese Medical Diagnostic and therapeutic Standard Results: Immediate post tx: IG = 97.6%, CG = 47.5% improved (P<0.01) Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: there was a very sign. difference in the effective rate between the IG and the CG
Zhu, Q (2003)92 Country: China Quality score: 4/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: 30 ds Final assessments: Immed. Post-tx N screened: not mentioned N randomized: 60 N completed tx: 60 N attended last fu: NR Eligibility criteria:; - inclusion: diagnosed using Chinese Medical Diagnostic and Therapeutic Standard; - exclusion: spinal stenosis, lumbar buttlock myofacial pain syndrom, caudal nerve tumor, epidural tumor, pradiculitis, deformity of sacrum vertebra | Mean age (SD/range): IG = 34.01 (0.18) vs. CG = 32.96 (0.22) yrs % of male: IG = 80.6% vs. CG = 79.3% Racial composition: Asian Work status: NR Other socio-demographics: Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc/joint disease Duration of Pain: Acute, subacute, chronic, IG = 4.8 mos; CG = 5.21 mos Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 31) – acu + moxibusion + autonomic traction of knee-chest: acupoint: jiajixue, add chibian, huantiao, fengshi, weizhong, yanglinquan, xuanzhong, taichongxue. Acupuncture retention 15 min +moxibusion autonomic traction for 15 min; 1 tx/d, 1 d rest/wk, 30 tx total Drop outs: B=0 CG (n = 29)– Acu + moxibusion : same as IG; same as IG Drop outs: B=0 | Outcomes: Pain: Pain, VAS, A, B Disability: NA Results: Baseline: NA Pain: IG = 4.42 (1.03); CG = 4.415 (0.1) Immediate post tx: NA Pain: IG = 1.57 (0.012); CG = 2.89 (0.026) Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: well being, B Results: Immediate post tx: IG = 93.5%, CG = 75.9% improved (P<0.05) Short term: NR Intermediate: NR Long term: NR Harms: NR

Table 1.6 Low Back Pain - Acupuncture - Mixed - Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
He (1997)93 Country: China Quality score: 4/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 20 ds Final assessments: immediately post tx N screened: 100 N randomized: 100 N completed tx: NR N attended last fu: NR Inclusion: LBP, fixed in location, limited ROM, worse in cold and raining weather. Exclusion: Kidney diseases or bone diseases confirmed by urine test and x-ray test. | Mean age (SD/range): NR, range 22-79 yrs % of male: IG = 42%, CG = 46% Racial composition: Chinese Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Acute to chronic, 5ds-6 mos Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 50)– Manual Acu + moxi + Chinese herbal medicine: De qi sensation was obtained. Moxibustion was used 2-3 times on the handle of the needles and needles were retained for 30 mins. Herbal formula was given daily; total of 20 tx- once/d up to 10 tx, two 5 d tx sessions Drop outs: NR CG (n = 50) – Chinese herbal Med: no description; same as IG Drop outs: NR | Outcome instruments: Pain: NA Disability: NA Results: Baseline: NA Pain: Disability: Immediate post tx: NA Pain: Disability: Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Results: Immediate post tx: % Cured- tx effect: IG = 82%, CG = 64%; %marked effective: IG = 10%, CG = 12%; % improved: IG = 6%, CG = 8%; No change: IG = 2%, CG = 16% Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: IG is better that CG alone for treating LBP with cold and dampness based on TCM diagnosis
Sakai, T (2001)94 Country: Japan Quality score: 8/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: 2 wks Final assessments: immediately post tx N screened: 71 N randomized: 68 N completed tx: 63 N attended last fu: NR Inclusion (1) LBP without sciatica, (2) at least 2-wk history of LBP, and (3) over twenty yrs old. Exclusion: neurological findings, pain/numbness in lower extremity; malignancy, infection/ inflammatory disease; fracture; lumbago due to urological , gynecological , digestive or cardio-vascular problem; pts who cannot stransverse oscillatory rot other conflicting/ongoing tx; problem of general condition; dementia; pregnancy | Mean age (SD/range): IG = 37.3 (12.5) vs CG = 36.2 (12) yrs % of male: IG = 64.5%; CG = 45.5% Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Lumbago (22), lumbar spondylosis (15), discopathy (9), acute LBP (3), spondylolysis (3), spondylolisthesi s (1), sacroiliitis (1) and un-classified (10). Duration of Pain: mixed, IG = 52.8 (6.11); CG = 93.9 Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 32) – E-Acu: Needling points chosen by palpation of quadratus lumborum and/or erector spinae, 2 points were used bilateraly, in total 4 points for each tx., 2 disposable needles used: 0.20 mm and 0.24 mm diam., 50 mm and 60 mm in length, needles inserted into muscles; 2 tx/wk for 2 wks, total 4 tx sessions Drop outs: 1 CG (n = 36) – TENS: stimulating points chosen by palpation of quadratus lumborum and/or erector spinae, 2 points were used bilateraly, in total 4 points for each tx; at freq. 1 Hz for 15 min adjusted to make contraction w/o pain; same as IG; Drop outs:4 | Outcomes: Pain: Pain relief scale (VAS-10 cm) before run in period; response rate of pain releif scale, n %; after run in period Disability: JOA score after 1 wk run in Results: Immediate post tx: Pain: IG = 5.3 (3), CG = 5.9 (3.4); NR % pts with no pain: IG = 13, CG = 10; n of pts with >50% pain reduction: IG 41.9, CG = 30.3 Disability: IG = 14.3 (2.2), CG = 14.4 (2.7) Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NA Results: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: There was no difference between groups in any parameter.
Thomas, KJ (2007)95 Country: UK Quality score: 9/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: 24 mos Final assessments: immediately post tx N screened: 298 N randomized: 239 N completed tx: 239 N attended last fu: NR Eligibility criteria:; - inclusion: Patients aged 18-65 yrs with N-S LBP of 4-52 wk duration; - exclusion: Possible spinal pathology, carcinoma, motor weakness, disc prolapse, past spinal surgery, bleeding disorders, or current Acu Tx | Mean age (SD/range): IG = 42 (10.8) vs. CG = 44 (10.4) yrs % of male: IG = 37.7% , CG = 42.5% Racial composition: IG (n = 100)- white; CG (n = 97.5) - white Work status: Full-time: IG = 51.6; CG = 56.3 Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Chronic, IG = 17.1 (13.5);CG = 16.7 (14.6) Severity of pain (Grading): (both grps): Bothersome BP in past wk (extreme): 56% Co-interventions: Moxa (17.7%), massage (42.2%), acupressure (12.8%), cupping (4.5%), Chinese herbs (4.5%), diet (11.3%), yoga EX (3.3%), relaxation (3.0%) | Groups IG (n = 159) – Acu: 177 acupoints bilaterally and unilaterally, needles 25-40 mm long and 0.20-0.30mm in diameter; max 10tx/pt Drop outs: C = 13, D= 12, E = 36 CG (n = 80) – Usual Tx: Mix of PT, Med, and back EXs; NR Drop outs: D =21, E = 21 | Outcomes: Pain: SF-36 Bodily Pain score; PPI of McGill questionnaire Disability: Oswestry Low Back Pain Disability – reported as % Results: Immediate post tx: Pain: IG = 60.9 (23), CG = 55.4 (25.4); IG = 2.43, CG = 2.77 ODI adjusted mean: 20.4 vs. 23.3 Short term: NR Intermediate: NR Long term, (12 montsh) Pain (PPI, adjusted mean): 2.44 vs. 2.51 ODI, adjusted mean: 20.1 vs. 20.6 | Outcomes: QoL/ well being: SF-36 Results: Immediate post tx: NR Short term: IG = 20.4, CG = 23.3 Intermediate: NR Long term: NR Harms: collected for acu grp only: one pts visited accident and emergency with symptoms of painc attack following tx; no SAE during the trial
Tsukayama, H (2002)96 Country: Japan Quality score: 7/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 2 wks Final assessments: imm. Post-tx N screened: 21 N randomized: 19 N completed tx: 19 N attended last fu: 19 Inclusion: LBP without sciatica, at least 2 wks history of pain and > 20 yrs of age Exclusion: radiculopathy of neuropathy, fracture, tumour, infection or internal disease, other general health problemsadn conflicting or ongoing txs. | Mean age (SD/range): IG = 47 (10) vs. CG = 43 (13) yrs % of male: IG = 11 %, CG = 20% Racial composition: Assuming 100% Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Chronic, IG = 7.9 (5.4), CG = 8.5 (9.05) yrs Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 9)– E-Acu:, insertion depth 20mm. e-stimulation was applied to the inserted needles freq of 1 Hz/15 min- then adjusted to max tolerable level, muscle contraction was observed. press tack needles were inserted after EA at 4/8 chosen points in each session and left in situ for several ds; 2tx/wk for 2 wks Drop outs: A = 1, B = 0 CG (n = 10) – TENS:. EA was applied in the same manner as IG. After each session a poulitice containing methy salicylic acid, menthol and antihistamine was prescribed to be applied at home in between treatmetns to the low back region; same as IG Drop outs: A = 0 B=0 | Outcome instruments: Pain: VAS (100mm)- average during the intervention period Disability: JOA Results: Baseline: Pain: NR Disability: IG = 16.3 (2.3), CG = 15.6 (3.7) Immediate post tx: Pain: IG = 56 (10), CG = 78 (10) Disability: IG = 18.6 (0.6), CG = 15.8 (1.2) Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Results: Baseline: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: One case of each: IG- (n = 5) transient aggravation, discomfort due to ress tack needles, pain on needle insertion, small subcutaneous bleeding; CG – (n = 3) transient aggravation , transient fatigue, itching with electrode
Zhang, Y (2007)97 Country: China Quality score: 4/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: 10 ds Final assessments: immediately post tx N screened: 120 N randomized: 120 N completed tx:120 N attended last fu: NR Eligibility criteria:; - inclusion: Low back pain; - exclusion: Osteoporotic; tumor; Spondylolysis with spondylolisthesis;Supp urative inflammation | Mean age (SD/range): IG1 = 37.73(5.62); IG2 = 39.57 (7.35); IG3 = 40.53 (8.27) yrs % of male: IG1 = 55; IG2 = 47.5; IG3 = 60 Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Unknown or mixed duration: IG1 = 2.32 yrs (0.54); IG2 = 2.78yrs (0.53); IG3 = 2.92 yrs (0.26) Severity of pain (Grading): NR Co-interventions: NR | Groups IG1 (n = 40) – E-acu: G6805 E-acu Therapy Instrument; 4-6Hz, 15min/d for 10 ds Drop outs: B= 0 IG2 (n = 40) – Acupoint injection of Danggui:NR; 0.5-1ml/d for 10 ds Drop outs: NR IG3 (n = 40) – acupoint injection of O_3_: German instrument; 30ug/ml x 3-5 ml/d for 10 ds Drop outs: NR | Outcomes: Pain: NR Disability: NA Results: Baseline: NA Pain: NR Immediate post tx: Pain: NR Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: Other: NA Results: Baseline: NA Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR Summary of results (if provided): acupoint injection of O3 is the best than other txs

Table 1.7 Low Back Pain - Acupuncture - Unknown - Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Lee, J (2007)98 Country: Korea Quality score: /13 Initial of reviewer: SG | Trial Design RCT Tx duration: 3 wks Final assessments: immediately post tx N screened: 33 N randomized: 31 N completed tx: 23 N attended last fu: NR Eligibility criteria:; - inclusion: Female Pts 20-50 yrs old with LBP and accompanied sciatic neuralgia; - exclusion: other S causes such as fracture, tumor or infection of lumbar, cauda equina syndrome, spondylolisthesis, spondylosis grade II- IV, osteoporosis, scoliosis, health examination, CLBP due to heavy labour. | Mean age (SD/range): NR % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: 100% with radiating pain Duration of Pain: Unknown, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 16)– Kuesu- point acu: Acu on B25, B26, & B60 with Kuesu point (3-cun from the sacrum center, paralleled to the 4th sacrum foramen) Raising, thrusting, twirling or rot techniques were used to gain “de-Qi”. Needles inserted 4-5cun 90° relative to skin surface; 4-5 tx/wk for 3wks, needle inserted for 11 min. Drop outs: A = 2 B = 6 CG (n = 15) – Non Kuesu-point acu: Acu on same points as IG without Kuesu point. On B25, B26; same as IG Drop outs: NR | Outcome instruments: Pain: Pain rating scale (0 -100) Disability: NA Results: Immediate post tx: Pain: 5.30 vs. 2.40 Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Results- mean: Immediate post tx Estimation Index of Backache (0 – 100): 0.45 vs. 0.26 Difference between before and after tx (after-before): 38.8 vs. 19.0 Pain elimination ratio (%): 73.3% vs. 40.0% on ROM test; 53.3% vs. 20.0% on motor test, and 66.7% vs. 30.0% on walking on heel test. Short term: NR Intermediate: NR Long term: NR Harms: NR
Li, Y (2006)99 Country: China Quality score: /13 Initial of reviewer: FY | Trial Design-RCT Tx duration: 1 month Fu duration (last assessment): immediately post tx N screened: NR N randomized: 77 N completed tx: 77 N attended last fu: 77 (attrition NR) Inclusion: adult without any major complications and diagnosis of prolapsed lumbar inter vertebral disc Exclusion: NR | Mean age (SD/range):NR years % of male: NR Racial composition: assumed all Asian Work status: NR Other socio-demographics: No data reported Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: LBP Cause of Pain: Specific: prolapsed disc Duration of Pain, mean (SD/range): NR Severity of pain (Grading): NR Current treatment/ co-intervention common in all groups: NR | Groups IG (n = 40)– Acupuncture, by therapist at Shenshu (BL23), Dachangshu (BL 25), Baliao (BL 31, 32, 33, 34), Zhibian (BL 54) combined with polarized light – treatment duration: 1 month CG (n = 37) – Western medication: Dikelake (75 mg) once daily—total treatment duration = 1 month | Outcomes (describe instrument used): Curative rate (markedly cured) Pain (VAS) Results- Immediate post tx: Pain-mean: Baseline: 6.05 (1.18) vs. 5.95 (1.22) Post tx: 2.28 (0.95) vs. 3.49 (1.45)—p < 0.05 % of pts with markedly cured status: 95% vs. 75% Short term: NA Intermediate: NA Long term: NA | Outcomes (describe instrument used): No other relevant outcomes reported
Wang, Z (2009) 100 Country: China Quality score: /13 Initial of reviewer: SG | Trial Design RCT Tx duration: 2 course NR Final assessments: immediately post tx N screened: NR N randomized: 139 N completed tx: NR N attended last fu: NR Inclusion: pts with senile radical xciatica Exclusion: NR | Mean age (SD/range): IG = 68 (3.5) vs. CG = 67 (3.7) yrs % of male: IG = 58.8%, CG = 59% Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Sciatica 100% with radiating pain Duration of Pain: NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 70)– E-Acu: acu points such as BL 24, BL 25, BL 26; 2 courses (possible 5-7 ds in each course) Drop outs: NR CG (n = 69) – TENS: skin electrode sticking at the PPT point of the nerve trunk connected with pulse current Drop outs: NR | Outcome instruments: Pain: NA Disability: NA Results: Baseline: Pain: NA Disability: NA Immediate post tx: AN Pain: Disability: Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: cure rate (QoL) at the end of each course Results: Immediate post tx: % improved: IG = 80%, CG = 44.9% Short term: NR Intermediate: NR Long term: NR Harms: NR Summary of results (if provided): end of 1 st course the cured rate was 41.1% vs. 29%
Wu, Y (2004)101 Country: China Quality score: 4/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: 20 ds Final assessments: immediately post tx. N screened: Not mentioned N randomized: 300 N completed tx: NR N attended last fu: NR Eligibility criteria:; - inclusion: diagnosed as lumbar intervertebral disc protrusion, 25-60 yrs, stransverse oscillatory rot using other tx or medicine, signed consent form; - exclusion: pts with spondylolysis, infection, all body collagen immune disease using glucocorticoid, pts whose symptoms became worse during the study. | Mean age (SD/range): NR % of male: NR Racial composition: Asian Work status: NR Other socio-demographics: Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc/joint disease Duration of Pain: NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG1 (n = 100) – E-acu: at Shiqizhui, yaoyangguan, huantiao, yanglingquan (affected side) + geshuxue + hegu + yinlingquan (two sides) for pts with cold dampness and hot dampness; + sanyinjiao for liver and kidney deficit. retention 20 min; 1 tx/d, 10 tx/course, 5 ds between courses x 2 courses, after 1^st^ course add lumbar traction (5min, 1tx/d, 10tx) Drop outs: unknown IG2 (n = 100) – Acu: same as IG1; same as IG1 Drop outs: unknown CG (n = 100)– Medicine: fenbid 75 mg/time; 1 tx/d,10tx/ course, 5 ds between courses x 2 courses Drop outs: unknown | Outcomes: Pain: NA Disability: NA Results: Baseline: NA Pain: NA Immediate post tx: NA Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: well being, B, using both Chinese and Western diagnostic and therapeutic standard for Lumbar intervertebral disc protrusion Results: Immediate post tx: IG1 = 88%, IG2 = 72% , CG = 76% improved Short term: NR Intermediate: NR Long term: NR Harms: NR

Table 1.8 Low Back Pain - Acupuncture - Unknown - Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Edelist, G (1976)102 Country: Canada Quality score: 2/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 2 ds Final assessments: immediatedy post tx N screened: NR N randomized: 30 N completed tx: NR N attended last fu: NR Inclusion: Pts with disc disease- not responding to conventional therapy including bed rest, analgesics, heat, and PT Exclusion: NR | Mean age (SD/range): NR % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc disease Duration of Pain: NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 15)– Acu: needles inserted bilaterally(Ta-ch'ang-yu: 3.6 cm lateral to the midline at a level between the 4th and 5th lumbarvertebrae- and the distal margin of the gastrocnemius muscle); needles were manip. until Te Chi was elicited- needles then attached to ES G68.5 and set to stimulate at a freq of 3-10 Hz with an intensity tolerable to pts. Needles were stimulated for 30 sec then removed; 3 tx over 2 ds Drop outs: NR CG (n = 15) – Sham acu: needles as IG inserted at level of L4-5 bilaterally, 15cm lateral to midline, needle in each leg 10cm below politeal fossa, 6cm lateral to midline, stimulated as IG; same as IG Drop outs: NR | Outcome instruments: Pain: Patients with no pain measured by VAS Disability: NR Results: Immediate post tx: n (%) of pts with no pain: IG = 7 (46.7%), CG = 6 (40%) Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Results: Baseline: NA Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR
Garvey, TA (1989)103 Country: U.S Quality score: 7/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 1 tx, NR Final assessments: 3 mo N screened: NR N randomized: 63 N completed tx: 63 N attended last fu: 63 Inclusion: pts treated for strain LBP (defined as non-radiating pain with normal neurologic examination, absence of tension signs and normal lumbosacral roentgenograms) with nonsteriodal anti- inflammatory agents, hot showers 2xd, and avoidance of activity that might aggrevate the pain for 4 wks (initial run in period) Exclusion: NR | Mean age (SD/range): total 38 yrs % of male: 65.1% total Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Mechanical strain Duration of Pain: NR Severity of pain (Grading): NR Co-interventions: hot shower twice a d and restricted physical activity-causioned against starting any EX program, same in all groups | Groups IG1 (n = 13)– TP lidocaine injection; one time tx Drop outs: 3 IG2 (n = 14) – TP: 0.75 ml of 1 % lidocaine and 0.75 ml of Aristospan (20 mg/ml), using a 21-gauge needle after and isopropyl alcohol wipe; one time tx Drop outs: 3 IG3 (n = 20) – Dry needling injection: single dry needle stick (i.e. acu) with a 21 gauge needle after and isopropyl alcohol wipe; one time tx Drop outs: 2 CG (n = 16) – Ethylchloride spray, followed by 20 seconds of acupressure using the plastic needle guard; one time tx Drop outs: 4 | Outcome instruments: Pain: Pain improvement- improved at C (ITT); Pain improvement- improved at C (completers only) Results: Immediate post tx: NR Short term: Pain: IG1 = 31%, IG2 = 26%, IG3 = 55%, CG = 50%; IG1 = 40%, IG2 = 45%, IG3 = 61%, CG = 66% Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR
Inoue, M (2001)104 Country: Japan Quality score: 10/13 Initial of reviewer: SG | Trial Design RCT Tx duration: single tx Final assessments: immediately post tx N screened: 21 N randomized: 16 N completed tx: 16 N attended last fu: NR Inclusion: Pts with lumbago who attended the university acu clinic as outPt and gave consent to attend to the trial. Exclusion: other S causes, systemic problems; pts who can’t stransverse oscillatory rot conflicting /ongoing tx; problem of general condition; (8) dementia; pregnancy | Mean age (SD/range): IG = 55.1 (18.8) vs. CG = 56.3 (18.2) yrs % of male: NR Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Lumbago Duration of Pain: NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 10)– Acu: one needling point chosen from lumbar area: most painful locus detected. Needles inserted and sparrow-picking technique performed for 20 sec. pts treated once time immediately before regular acu tx; single tx Drop outs: 0 CG (n = 6) – Sham Acu: One needling point was chosen from lumber area: most painful locus was detected, as same as RA group, mimicked needle insertion: tapped head of needle guide tube, and then gesture of needling was performed for 20 sec. Pts were treated one time immediately before regular acu tx; single tx Drop outs: 0 | Outcome instruments: Pain: VAS of(100 mm) pain at the most restricted action Results: Baseline: Pain: IG = 72.2 (19), CG = 68.2 (12.8) Immediate post tx: Pain: IG = 37.3 (24.4), CG = 64.1 (13.5) Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR Summary of results (if provided): There was difference between the IG and CG
Kawase, Y (2006)105 Country: Quality score: 10/13 Initial of reviewer: SG | Trial Design RCT Tx duration: NR Final assessments: immediately post tx N screened: NR N randomized: 64 N completed tx: 64 N attended last fu: NR Inclusion: NR Exclusion: Those who do not have good overall physical status Those who were found inappropriate for acu therapy (based on hand examination (e.g., those with pathological reflex, pain while resting, pain when needling) | Mean age (SD/range): IG1 = 47.2 (17.6), IG2 = 57.8 (13), IG3 = 54.5 (16.3), CG = 51.7 (18.1) yrs % of male: IG1 = 42%, IG2 = 77%, IG3 = 60%, CG = 47% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: NR, IG1 = 51 (65), IG2 = 48 (49.8), IG3 = 47.4 (74.1), CG = 49.3 (69.9)-(not sure if values measured in d, wks, mo, or yrs)-SG Severity of pain (Grading): NR Co-interventions: Point therapy (BL40) | Groups IG1 (n = 12)– Body Acu pole tx + low freq. acu: CV12, LR14, ST25, CV6, BL10, GP20, BL11, GB21, BL13, BL 14, BL 20, BL23, BL25, point therapy: BL40, Low freq. acu: BL23(-) to BL40(+), 5Hz, 2V, 5 min, depth 5-7 mm; 1 tx Drop outs: 0 IG2 (n = 13) – Body acu pole tx: sham acu:BL20, BL23, BL25; NR Drop outs: 0 IG3 (n = 20) – Low freq. acu: 30mm No18. or Np 20 disposal stainless steel needle; NR Drop outs: 0 CG (n = 19) – Sham Acu: NR – possibly same as IG2-SG; NR Drop outs: 0 | Outcome instruments: Pain: Therapeutic effectiveness (VAS) Disability: Activities of daily living (numeric data not shown) Results: Immediate post tx: Pain: 51.0 (65.0) vs. 48.0 (49.8) vs. 47.4 (74.1) vs. 49.3 (69.9) Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NA Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: Significant improvement (p<0.05) in pain (in terms of VAS scores) and ADL (in terms of JOA scores) was found for all groups except for CG
Kurosu, Y (1979 & 1980)106 Country: Japan Quality score: 3/13 Initial of reviewer: SG | Trial Design RCT Tx duration: NR Final assessments: 3 mos N screened: 20 N randomized: 20 N completed tx: 20 N attended last fu: 20 Inclusion: Pts with LBP or the LB and sacral region. Exclusion: NR | Mean age (SD/range): majority range 40 - 50 yrs % of male: IG 1 & 2a = 50%, IG 1 & 2b = 55% Racial composition: Asian Work status: NR Other socio-demographics:NR Co morbidities:NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Non-S Duration of Pain: NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG 1a (n = 10) Acu: needles retained for 10 min in 6-8 points in LB region: BL23, 24 25, 26, 27, 31, 52, and 3 extra points,needles (50 mm x 0.25 mm) inserted at depth of 2-4 cm depended on const. of pts; 1b (n = 10) – same as 1a + needle retention in abdominal points CVF4, 12 and bilateral ST25, depth of insertion 1-1.5 cm for 10 min.; NR Drop outs: 0 CG 2a (n = 10) Garlic moxibusion(acu?): same points as IG, detail NR, put garlic on surface of body and burn moxa on that; 2b (n = 10) –simple needle insertion: needle inserted and removed at same points as IG +needle retention as IG 1b ; NR Drop outs: 0 | Outcome instruments: Pain: Pain recovery score by questionnaire: 2^nd^ visit before 2^nd^ tx; 4^th^ visit before 4^th^ tx Results: Immediate post tx: NR Short term: IG 1a = 0.58 (0.64), 1b = 1.18 (0.747), CG 2a = 0.42 (0.66), 2b = 0.22 (0.253) ; IG 1a = 0.865 (0.799), 1b = 0.625 (0.648), CG 2b = 0.22 (0.253) Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Results: Immediate post tx: NR Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: In tx of LBP, eedle retention technique was much superior to simple needle insertion technique.
Mencke (1988)107 Country: Germany Quality score: 9/13 Initial of reviewer: SG Exclude: Shoulder and Back | Trial Design RCT Tx duration: 3 wks Final assessments: 8 wks N screened: 75 N randomized: 75 N completed tx: 75 N attended last fu: NR Inclusion: Pts have previously been treated unsuccessfully (GP, orthopedic, physiotherapist), no involvement in other therapies Exclusion: NR (anyone not meeting inclusion criteria) | Mean age (SD/range): Both grps together: 49.4, Range 29-79 % of male: 49.3% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: No Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S + disc herniation Duration of Pain: unknown Severity of pain (Grading): VAS (0-10) but NR Co-interventions: none | Groups IG (n = 40)– Typical AP: Needles were placed within the affected segment near AP and TPs; 6 tx sessions over 3 wks, 6-12 needles/session, AP needles 0.2-3cm depth Drop outs: none CG (n = 35) – Atypical AP: Needles were placed within the affected segment but far away from AP and TPs; Session 1: 5 mins, session 2: 10 mins, session 3: 15 mins, session 4 +>: 20 mins Drop outs: none | Outcomes: Pain: VAS Pain scale Results: Immediate post tx: Pain: 41.0 vs. 83.0 Disability: 0.0043, vs. 0.0461 (abduction), IG = 0.0044, CG = 0.001(anteversion), IG = 0.0177, CG = 0.0757(retroversion ), IG = 0.0567, CG = 0.4609 (outer rot), IG = 0.0001, CG = 0.2324 (inner rot),IG = 8.0, CG =-0.3 (anteversion of head) Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Results: Immediate post tx: NR Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: highly signif. differences in improvement between typically & atypically treated Pts

Table 1.9 Low Back Pain - Manipulation – Acute/Sub-acute - Specific Pain – No Studies

Table 1.10 Low Back Pain – Manipulation – Acute/Sub-acute - Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Alaksiev, A (1996)108 Country: Bulgaria Quality score: 3/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 20 ds Final assessments: immediately post tx N screened: 64 N randomized: 65 N completed tx: NR N attended last fu: NR Inclusion: NR Exclusion: NR | Mean age (SD/range): NR % of male: balanced Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: N-S Duration of Pain: Acute, Sub-acute, NR Severity of pain (Grading): NR Co-interventions: NR | IG1 (n = 22) – High velocity, low amplitude technique: NR; 2-4 sessions, 20 ds Drop outs: NR IG2 (n = 21) – Post-isometric relaxation; 12 sessions Drop outs: NR CG (n = 21): shame manipulation; 2-4 tx | Outcomes: Disability: NA Results: Baseline: Disability: NR Immediate post tx: Disability: Short term: NR Intermediate: NR Long term: NR No numeric data given | Outcomes: QoL/ well being: NR Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR
Hadler NM (1987)109 Country: US Quality score: 7/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: NR Final assessments: immediately post tx N screened: 57 N randomized: 54 N completed tx: NR N attended last fu: NR Inclusion: Pts aged 18-40 yrs with acute LBP (≤ 1 mo), no other episode of back pain in previous 6 mo, not work-related pain, no previous surgery Exclusion: NR | Mean age (SD/range):NR(tr ial intended for a younger adults) % of male: 48% total Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: NS Duration of Pain: Acute ≤ 2 wks: n = 13 Severity of pain (Grading): NR Co-interventions: NR | IG (n = 28) – Mobilization: Pt was positioned first on the right and then on the left side; the operator grasped both knees with one arm while pressing down on the on the pts’ lower spine with the opposite hand; then the subjects legs were gently flexed on the hips twice; NR Drop outs: NR CG (n = 26) – Manipulation: Pt was positioned on right, then on the left side; then pt positioned in a spinal rot position, shoulders and the face up to the ceiling and pelvis rotated down toward the table; a long lever HV thrust was applied to the lower spine while stabilizing the thorax; NR Drop outs: NR | Outcomes: Pain: NR Disability: RMDQ Results: Immediate post tx: Disability: IG = 9.1 (5.3), CG = 3.9 (4.3) Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: Manipulation was more effective than Mob at reducing disability score in the first wk of tx (time and tx interaction significant p < 0.04) for those with duration of pain for 2-4 wks (longer pain duration at entry)
Hoiriis K (2004)110 Country: Mariette, GA Quality score: 8/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 2 wks Final assessments: 3 mos N screened: 535 N randomized: 156 N completed tx: 110 N attended last fu: 110 Inclusion: 21 - 59 yrs old with uncomplicated LBP of 2 - 6 wks duration Exclusion: Previous spinal surgery, spinal fractures, spinal stenosis, and known or suspected disk herniation; previous LBP within 18 mos; neuropathy; spondylitis; vascular disease; malignant disease; cervical complaint; pregnancy; and personal injury litigation. | Mean age (SD/range): IG1 = 42.2 (9.7), IG2 = 40.5 (10.1), CG = 43.1 (9.8) yrs % of male: 56.7% total Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: IG1 = 0.36 (0.6), IG2 = 0.46 (0.64), CG = 0.58 (0.67) Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Sub-acute, IG1 = 3.7 (1.3), IG2 = 3.6 (1.5), CG = 3.8 (1.4) wks Severity of pain (Grading): NR Co-interventions: NR | Groups IG1 (n = 50)– Chiro adjustments and medical placebo: upper cervical and lumbar, sacral, or pelvic adjustments performed manually with HVLA thrust; 7 visits of chiro, 2 wks Drop outs: NR IG2 (n = 53)– muscle relaxants and sham adjustments: designed to mimic chiro adjustments; 2 capsules, 3 times daily from A, B, C, D bottles, 2 wks Drop outs: NR CG (n = 53) – medical placebo and sham adjustments: same as IG1 and IG2; Drop outs: NR | Outcomes: Pain: VAS (10 cm) Disability: Oswestry Results- Immediate post tx: Pain: IG1 = 2.44 (2.22), IG2 = 2.73 (2.15), CG = 3.18 (2.4) Disability: IG1 = 17.02 (13.75), IG2 = 16.99 (12.18), CG = 19.35 (13.7) Short term: VAS: IG1 = 1.71 (1.88), IG2 = 2.24 (2.23), CG = 2.21 (2.02) ODQ: IG1 = 11.94 (11.93), IG2 = 16.04 (16.12), CG = 16.32 (12.95) Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR
Hsieh, C (2002)111 Country: California, US Quality score: 4/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 3 wks Final assessments: 6 mos N screened: 206 N randomized: 200 N completed tx: 184 N attended last fu: 178 Inclusion: 18 yrs or older, LBP duration of more than 3 wks-6 mo for current episode or a pain- free period of at least 2 mo in preceding 8 mo for recurrent Exclusion: pregnancy; serious medical problems, definable neurologic abnormalities in the lower extremities; spine disorders with bony lesions, with radiographs were taken as clinically indicated; sign. mental disorders; obesity; leg pain with positive nerve root tension; history of lumbar surgery | Mean age: 48 yrs % of male: 65.4% Racial composition: White: 71.7% Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Sub-acute, CG = 10.7 (6.6), IG1 = 11.8 (6.8), IG2 = 11.8 (7.2), IG3 = 11.5 (7.2) wks Severity of pain (Grading): NR Current tx/ co-intervention: 10% reported use of otc pain Meds. 6 pts reported 8 visits to health care practitioners. Among these visits, 2 were related to LBP. | Groups CG (n = 48)– Back school program: videos; instructions and supervised home programs 1 x/wk for 3 wks Drop outs: mB = 6 IG1 (n = 51) – Myofascial therapy: sprays and stretches after isometric contraction at 50-70% MVC; 3 x/wk for 3 wks Drop outs: 2 IG2 (n = 49) – SM manipulation: HVLA maneuver in the lumbar / sacroiliac Drop outs: B = 3,D = 5 IG3 (n = 52) – SM + myofascial therapy Duation as other grps Drop outs: B = 4 | Outcomes: Pain: VAS Disability: Roland Morris activity sclae Results- Immediate post tx: Pain: CG = 2.13 (1.28), IG1 = 2.78 (1.82), IG2 = 2.58 (1.93), IG3 = 2.04 (1.35) Disability: CG = 4.26 (3.52), IG1 = 5.8 (5.12), IG2 = 4.42 (4.92), IG3 = 3.73 (3.76) Short term: NR Intermediate: Pain: CG = 2.29 (1.98), IG1 = 2.99 (2.28), IG2 = 2.4 (2.41), IG3 = 2.24 (2.01) RMAS: CG = 3.48 (3.86), IG1 = 5.06 (4.78), IG2 = 3.29 (4.73), IG3 = 3.56 (3.46) Long term: NR | Outcome instruments: QoL/ well being: NR Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: 23 pts reported adverse effects from tx-mostly transient exacerbations of symptoms, n = 2 claimed that IG2 aggravated symptoms, n = 1 constant tinnitus in IG1
Morton, J (1999)112 Country: US Quality score: 4/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 4 wks Final assessments: 3 mos N screened: NR N randomized: 29 N completed tx: 29 N attended last fu: 29 Inclusion: 18-70 yrs with acute mechanical LBP of approx. 4 wks or less. Pain located between T12 and the gluteal fold (might radiate to one lower limb) Exclusion: Contraindications for manipulations neoplastic disease, bone disease, inflammatory arthritis, advanced diabetes mellitus, vascular abnormalities, visceral arterial disease, congenital generalized hypermobility, severe nerve root pain, claimants. | Mean age (SD): IG = 42.9 (9.1) vs. CG = 46.4 (9.0) yrs % of male: IG = 27%, CG = 43% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Non-S Duration of Pain: Acute, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 15)– Manipulation + Exercise: HV thrust to joint to briefly force beyond its restricted ROM or sudden HV short-amp motion delivered at pathological limit of accessory ROM to gap the joint, manipulation L1-L5/L5-S1 traction gap, EXs designed to re-educate multifidus musculature in its stabilizing role; 8 tx, 4 wks Drop outs: NR CG (n = 14) – Exercise: Same as IG, training in hands- knee position, gradually to standing position with lumbar spine in neutral and enhanced by use of pelvic stabilizer; same as IG Drop outs: NR | Outcome instruments: Pain: VAS (0 – 100) Disability: Roland-Morris Disability Results-Baseline: Pain: IG = 49.73 (23.62), CG = 46.57 (25.1) Disability: IG = 10.6 (5.23), CG = 10.07 (6.4) Immediate post tx: Pain: IG = 2.4 (3), CG = 25.43 (17.34) Disability: IG = 1.93 (2.52), CG = 6 (5.22) Short term: AVAS-IG = 0 (0), CG = 13.57 (9.4) RMD: IG = 0.33 (0.82), CG = 3.64 (2.8) Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Results: NA Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: Pts who receive manipulation with EXs for acute LBP of mechanical origin will improve more and faster than pts who receive an EX program alone.
Pope, M (1994)113 Country: US Quality score: 5/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 3 wks Final assessments: 3 wks N screened: NR N randomized: 150 N completed tx: 148 N attended last fu: 148 Inclusion: ages 18-55 yrs; general good health; LBP between 3 wks-6 mo; free from LBP for minimum 3 wks Exclusion: pregnancy; sciatica; neurologic deficits, loss of sensation, strength and reflex; no prior vertebral fracture, tumor, infection or spondyloarthropathy; no prior back surgery; Davenport weight index greater than 33; no prior MT for this episode of LBP | Mean age (SD/range): 32 yrs % of male: 62% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: NS Duration of Pain: Mix Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 60)– Manipulation: dynamic short level, HVLA thrust on lumbar spine/ sacroiliac joint; 3 x/wk for 3 wks Drop outs: B = 17 CG (n = 30) – Soft-tissue massage: Effleurage conducted with Pt in prone position; 15 min/tx, 3 x/wk for 3 wks Drop outs: B = 10 IG2 (n = 30) -TMS: max 91 mA, 4 electrodes on back in area, for 8 hrs/d; 1 hr at a time; 1x/wk for 3 wks Drop outs: B = 10 IG3 (n = 30) – Lumbo sacral corset r max. 10 min at a time, 3 x/d; 1x/wk for 3 wks Drop outs: B = 6 | Outcomes: Pain: 10 cm VAS Disability: Results- Immediate post tx (after 4 wks): Pain change from baseline: IG = -24.1 (27), CG = -17.2 (25.1), IG2 = -9.6 (30), IG3 = -15.9 (27) VAS at 4 wks, mean: IG = 8.61; CG = 7.23; IG2 = 6.86; IG3 = 5.28 Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Other: ROM-modified Schober’s test: Flexion; Extension Immediate post tx: -mean change: IG = 0.38 (1.25), CG = - 0.08 (1.2), IG2 = - 0.02 (0.82), IG3 = 0.33 (0.93); IG = -0.29 (0.59), CG = -0.32 (0.63), IG2 = 0.63 (0.89), IG3 = -0.27 (0.72) Short term: NR Intermediate: NR Long term: NR Harms: NR
Postacchini (1988)114 Country: USA Quality score: 3/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: One session Final assessments: 3 mos N screened: 1880 N randomized: 95 N completed tx: 69 N attended last fu: NR Inclusion: LBP; presence of palpatory cues indicating that manipulation might be successful; absence of psychosocial problems that might affect tx outcome, absence of contraindications for vertebral manipulation; absence of previous experience with manipulative therapy. Exclusion: Pregnancy, previous experience with manipulation, disability income, pending litigation, previous back surgery, obesity, drug or alcohol abuse, and pain not treatable by manipulation of the lumbosacral area. | Mean age (SD/range): IG = 30.1 (8.4) vs. CG = 32.1 (9.8) yrs % of male: 59% total Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: N-S Duration of Pain: Acute/Sub-acute, IG = 30 (27.7) ds, CG = 19.6 (20.4) ds Severity of pain (Grading): NR Co-interventions: NR | IG (n = 56) – Rotational manipulation: Rotational manipulation of the lumbosacral spine; 1 tx Drop outs: NR CG (n = 39) – Soft-tissue massage; 1 tx Drop outs: NR | Outcomes: Pain: % pts reporting pain (severity level) Disability: Results-Baseline: Pain: NR Disability: NR Immediate post tx: Pain: Pts reporting improvement in amount of pain 84% in IG vs. 68% in CG Disability:NR Short term: no pain data could be used. Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Other: Straight leg raising (°) Immediate post tx: Improvement: 3.3 vs. – 0.5 Short term: Improvement 7.8 vs. 8.8 Intermediate: NR Long term: NR Harms: NR Summary: at discharge there was no significant difference between groups- tx was effective for 88% vs. 86% of pts
Postacchini (1988)115 Country: Italy Quality score: 6/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: Final assessments: 6 mos N screened: 459 N randomized: 398 N completed tx: 375 N attended last fu: NR Inclusion: Pts presenting at two LB clinics, 17-58 yrs Exclusion: BP related to neo-plastic or infectious diseases of the spine, pregnancy, nursing women, pts with serious general diseases, psychiatric disturbances, medico-legal litigation | Mean age (SD/range): NR % of male: 50.5% total Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: N-S Duration of Pain: Mixed, NR Severity of pain (Grading): NR Co-interventions: NR | IG1 (n = 87) – Manipulation: standard technique; 7 tx for 1^st^ wk, then 2 tx for up to 6 wks IG2 (n = 81) – Drug therapy: Diclophenac “full dose”; 10-20 ds IG3 (n = 78) – Physiotherapy: massage, electrotherapy, infrared, etc.; 7 tx/wk for up to 3 wks CG1 (n = 29) – Bed rest: NR; 15-24 hrs for up to 8 ds CG2 (n = 50) – Back school: NR; 4 sessions in 1 wk CG3 (n = 73) – Placebo gel: NR; 2 tx/ds for up to 2 wks Drop outs: Total lost to follow-up = 23 | Outcomes: Mean improvement, Results: Immediate post tx: Not presented at this table. Short term: Acute: 9.7 vs. 10.7 vs. 8.4 vs. 7.5 vs. 7.3 Chronic: 2.6 vs. 2.2 vs. 4.2 vs. 4.6 vs. 1.2 Acute with chronic history: 6.8 vs. 8.7 vs. 9.9 vs. 10.4 vs. 5.4 Acute with radiating pain: 9.2 vs. 8.7 vs. 6.0 vs. 5.7 vs. 5.1 Chronic with radiating pain: 6.2 vs. 7.5 vs. 6.4 vs. 2.8 vs. 2.1 Intermediate: (data reported but not presented in this table) Long term: NR | Outcomes: QoL/ well being: NR Results:NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: in pts with acute improvement initially observed in SM grp (not at 6 mos fu, with no diff between tx grps); in pts with chronic pain best result was achieved with PT at short term and BSP at 6 mos fu.
Rasmussen, G (1979)116 Country: Denmark Quality score: 2/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 2 wks Final assessments: immediately post tx, and 1 yr N screened: NR N randomized: 24 N completed tx: 24 N attended last fu: NR Inclusion: Male outPts, 20-50 yrs of age with LBP, without signs of root pressure; duration less than 3 wks; no tx except analgesics prior to the trial Exclusion: contraindications to manipulation | Mean age (SD/range): 34.9 (7.3) yrs (total) % of male: 100% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: NR Duration of Pain: Acute, NR Severity of pain (Grading): NR Co-interventions:NR | Groups IG (n = 12) – Short wave: NR; 3 times/wk for 2 wks Drop outs: B = 2 (total) CG (n = 12) – Manipulation: Rotational manipulation in the pain free direction; as IG | Outcome instruments: Pain: Restoration (n of pts with >50% pain reduction) Disability: Results: Immediate post tx: Pain: IG = 3, CG = 11 Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Other: Schober’s test Immediate post tx: pts with improvement: 12 vs. 6 pts with no improvement: 0 vs. 6 Short term: NR Intermediate: NR Long term: all restored pts were free of sympomes for at least one yr Harms: NR
Sanders GE (1990)117 Country: US Quality score: 7/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: one tx Final assessments: immediately post tx N screened: NR N randomized: 18 N completed tx: NR N attended last fu: NR Inclusion: Pts with acute LBP (< 2 wks) naïve to chiropractic manipulation and had not taken any pain Med for 48 hrs prior to the study enrollment Exclusion: NR | Mean age (SD/range): NR % of male: 50% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: NS Duration of Pain: Acute, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 6)– SM: A single HVLA adjustive SM at the L4/L5-S1 spinal region; one tx Drop outs: NR CG (n = 6) – Sham: light physical contact at the L4/L5-S1 spinal region; one tx Drop outs: NR CG2 (n = 6) – No tx; NA; NA Drop outs: NR | Outcome instruments: Pain: VAS Results: Baseline: Pain: IG = 2.67 (0.52), CG = 2.33 (0.52), CG2 = 2.17 (0.41) Immediate post tx: Pain: data presented in graphs- not used in this report. Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Other: plasma endorphin levels Results: Baseline: NA Immediate post tx: NA Short term: NA Intermediate: NR Long term: NR Harms: NR Summary: there was a significant reduction of pain in manipulation grp but not in the other grps
Shah, M (1989)118 Country: United Kingdom Quality score: Not applicable (abstract only) Initial of reviewer: SG | Trial Design RCT Tx duration: NR Final assessments: immediately post tx N screened: NR N randomized: 16 N completed tx: NR N attended last fu: NR Inclusion: pts with acute back pain Exclusion: NR | Mean age (SD/range): NR % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Acute, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 10)– Manipulation: NR; 7 ds (assumed) Drop outs: NR CG (n = 6) – Naprosyn (oral Med): NR; 7 ds (assumed) Drop outs: NR | Outcomes: Pain: pain rating scale at d 0 – 7- no numeric data is reported Disability: disability questionnaire at d 0, wk 1, and wk 4 – no numeric data reported Results: Immediate post tx: Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR General imporvement Results: Immediate post tx: at d 7, 50% vs. 83% improved (data for wek 4 was incomplete) Short term: NR Intermediate: NR Long term: NR Harms: NR
UK BEAM trial; Russell I (2004)119 Country: United Kingdom Quality score: 5/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 4-8 wks Final assessments: 9 mos N screened: 3535 N randomized: 1334 N completed tx: NR N attended last fu: NR Inclusion: Pts aged 18-65 yrs with LBP (RMDQ ≥ 4) who had experienced the pain daily for past mo Exclusion: Serious spinal disorder (malignancy, OP, AS, cauda equina, infection, or compression), previous spinal surgery, severe mental disorder, CVD, hypertension (systolic blood pressure > 180 mm Hg and diastolic > 105 mm Hg), anti- coagulant Tx, steroids, RMDQ ≤ 3, English literacy | Mean age (SD/range): 43.1 (11.3) yrs (total) % of male: 43.2% total Racial composition: 95.8% White Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: N-S Duration of Pain: Acute Severity of pain (Grading): NR Co-interventions: NR | IG1 (n= 338) – GP: Based on UK National Acute BP Guidelines, Drop outs: n = 349 (total) CG1(n= 310) – Exercise; 8 sessions for 4-8 wks IG2 (n = 180) – Private manipulation: techniques used by chiropractitioner IG3 (n = 173) – manipulation - NHS-: as IG2 in NHS premises CG2 (n = 172) – Private-M + Exercise: as above CG3 (n = 161) NHS- M + Exercise: as IG2 and CG | Outcome instruments: Pain & Disability: reported as adjusted means-values not shown Results: CG1 (1.4, 95% CI: 0.6, 2.1) and IG2 (1.6, 95% CI: 0.8, 2.3) improved disability compared to GP immediately after the tx; IG2 improved disability at wk 9 post-tx (1.0, 95% CI: 0.2, 1.8) vs. IG1; for CG2, this improvement immediately after the tx was 1.9 (95% CI: 1.2, 2.6) and 1.3 (95% CI: 0.5, 2.1) at 9 mo after the tx; no difference between IG2 vs. IG3 | Outcomes: QoL/ well being: Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: No SAE occurred. Other AE was NR.

Table 1.11 Low Back Pain – Manipulation – Chronic - Specific Pain---no trials

Table 1.12 Low Back Pain – Manipulation - Chronic - Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Biedermann F (1980)120 Country: Korea Quality score: 3/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: NR Fu duration: 3 mos N screened: 1649 N randomized: NR N completed tx: NR N attended last fu: 59 Inclusion: Sudden onset usually associated with trauma, recent onset usually of 2 or 3 wks, abnormally low SLR tests Exclusion: Pregnancy, disorders of the spinal cord or cauda equina, advanced occlusive vertebral artery disease, spinal disease including congenital defects, marked spinal instability, herniated nucleus pulposus, osteoporosis, ankylosing spondylitis | Mean age (SD/range): IG = 31.4 (9.19) vs. CG = 29.7 (5.58) yrs % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: NR Duration of Pain: NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = NR)– Rotational manipulation: pt’s thoracic and lumbar spine extended and rotated in intent to stretch paravertebral structured in lumbosacral area Drop outs: NR CG (n = NR) – Soft-tissue massage: Pt and manipulator assumed same relative positions, but rotal movement of the vertebrae was minimized while the lumbosacral paravertebral areas were massaged. Drop outs: NR | Outcomes: Pain: Duration or relief (mean in ds) Results: Immediate post tx: Pain: NR Short term: IG = 8.01 (2.02), CG = 2.94 (0.52) Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Spinal flexibility: (numeric data NR) Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR Note: patitent who responded to SM tend to be older at start of LBP compre to those who were not.
Cote P (1994)121 Country: Canada Quality score: 4/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: one session Final assessments: post- tx N screened: NR N randomized: 30 N completed tx: 30 N attended last fu: 30 Inclusion: Pts with mechanic CLBP > 2 mo Exclusion: seronegative spondyloarthropathy or rheumatoid arthritis, lumbar radiculopathy, hip pathology, abdominal/pelvic organ pathology, pregnancy, current use of muscle relaxants or anti- inflammatory drugs | Mean age (SD/range): 31 (7.15) yrs total % of male: IG = 37.5%, CG = 71.4% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Mechanical Duration of Pain: Chronic, 74 (83.3) mo (total) Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 16) – Mobilization: side- lying position, rot force was created at the lumbo-sacral junction or sacroiliac joints; joint taken to its limit of passive motion and HVLA thrust applied through the joint producing an audible sound; one session Drop outs: 0 CG (n = 14) – Manipulation: a long lever HV thrust applied to the lower spine while stabilizing the thorax in side lying and prone position ; one session Drop outs: 0 | Outcomes (instrument used): Pain: PPT: L5 tender point; SI ligament tender point; gluteus tender point Results: Immediate post tx: PPT IG = 5.6 (2.1), CG = 5.0 (2.9) SI IG = 5.6 (2.1), CG = 5.5 (3.1) Gluteus pain IG = 5.6 (2.2), CG = 5.2 (2.7) Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Results: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: The two groups did not differ in mean PPT scores for the three myofascial points (L5 tender point, SI ligament tender point, and gluteus tender point); ANOVA indicated no SS time*tx term interaction (P > 0.267)
Giles, LG (2003)25,26 Country: Australia Quality score: 6/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 9 wks Final assessments: 1 yr N screened: 533 N randomized: 115 N completed tx: 69 N attended last fu: 62 Inclusion: pts at least 17 yrs old with uncomplicated mechanical spinal pain for minimum of 13 wks, for long term fu (> 1 yr), those who received randomly allocated tx during 9 wk tx period Exclusion: pts with nerve root involvement, spinal anomalies (other than sacralization or lumbarization), pathology other than mild to moderate osteroarthrosis, spondylolisthesis of L5 or S1 exceeding Grade 1, previous spinal surgery, | Mean age (SD/range): IG1 = 23.8 (4.8), IG2 = 25 (8.1), CG = 29.5 (2.07) % of male: IG1 = 55.9%, IG2 = 51.4%, CG = 57.5% Racial composition: NR Work status: NR Other socio-demographics: 25.7% Pensioner /Unemployed Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: chronic (> 13 wks) Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 36)– Acu: TP & distal analgesia producing sypatholytic acu points- insertion depth 20-50 mm, 2 tx/wk up to 9 wks Drop outs: B = 14, E = 6/20 IG2 (n = 36) – Spinal manipulation: HVLA thrust; 20 min/session, 2 tx/wk up to 9 wks Drop outs: B = 11, E= 4/23 CG (n = 43) – new Med: Celecoxib/Celebrex (200 - 400 mg/d), Rofecoxib/Vioxx (12.5 - 25 mg/d), paracetamol/acetami nophen (500 mg tablets 2-6/d up to 4 g/d) Drop outs: B = 21, E = 12/19 | Outcome instruments: Pain: VAS (1 - 100)- ITT Disability: Oswestry Back Results: Immediate post tx: Pain: IG1 = 4 (3.7), IG2 = 3 (5.2), CG = 5 (3.7) Disability: IG1 = 26 (20.74), IG2 = 14 (24.4), CG = 32 (23.7) Short term: NR Intermediate: Long term: Disability IG1 = 13 (22.9), IG2 = 16 (17.8), CG = 24 (25.2) | Outcome instruments: QoL/ well being: NR Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: N=22, 13 in IG1, 4in IG2, 5 in CG, n=1 committed suicide after end of tx; most frequent AEs were hematoma and bleeding
Giles, LGF (1999)122 Country: Australia Quality score: 1/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 3-4 wks Final assessments: immediately post tx N screened: 875 N randomized: 69 N completed tx: not clear N attended last fu: NR Inclusion: pts suffering from spinal pain for at least 13 wks; age of at least 18 yrs Exclusion: Nerve root involvements; spinal anomalities; pathology other than mild to moderate osteoarthrosis; previous spinal surgery and leg length inequality of >9mm with postural scoliosis | Mean age (SD/range): IG1 = 46.5 (9.6), IG2 = 42.5 (9.6), CG = 35 (14.1) yrs % of male: IG1 = 35%, IG2 = 53%, CG = 19% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NA Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Chronic(13 wks), IG1 = 7.5 (10.4), IG2 = 6 (5.9), CG = 5 (9.6) yrs Severity of pain (Grading): NR Co-interventions: NR | Groups IG1 (n = 18)– Acu: treating clinician decided which form of acu taken-HWATO Chinese disposible acu guide tube needles 50mm long with a gauge of 0.25 mm for 20; 6 tx over 3-4 wks Drop outs: 26 IG2 (n = 32) – Manipulation: Spinal manipulation was performed to be safe and appropriate by the chiropractor for the spinal level of involvement only. A HVLA SM was performed; as IG1 Drop outs: 13 CG (n = 19) – Medication: tenoxican (20mg/d) and ranitidine (50mg x 2/ d); 15-20min/ tx over 3-4 wks Drop outs: 10 | Outcome instruments: Pain: Pain (VAS) at time A, B (change from baseline) Disability: Owstery Disiablity Index at A, B(change from baseline) Results: Immediate post tx: Pain, mean change: -1.0 vs. - 5.0 vs. -1.0 Disability, mean change: -7.0 vs. - 16.5 vs. -0.4 Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: SM more effective than acu or Med; overall 33 pts (43%) had to change to another intervention after study period because of inefficacy or side effects.% of necessary crossing over differed significantly (p = 0.002) with respect to 3 interventions, manipulation 22.2%, acu 60%, Med 62%
Haas, M (2004)123 Country: US Quality score: 7/13 Initial of reviewer: SG | Trial Design-RCT-4x2 factorial design – dose response of SM Tx duration: 3 wks Final assessments: immediately post tx N screened: 201 N randomized: 72 N completed tx: 72 N attended last fu: 67 Inclusion: Current episode of CLBP (> 3 mos) Must be 18 yrs and older and have English literacy Exclusion: prior chiro care in 3 mo before baseline; contraindications to SM; involvement in litigation for a health problem/non-compliance | Mean age (range): IG1 = 44 - 54 yrs, % of male: IG1 = 56%; IG2 = 50%, IG3 = 33%, IG4 = 44% Racial composition: majority (> 75%) White non-Hispanic Work status: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Non-S Duration of Pain: Chronic Severity of pain (Grading): NR Co-interventions: NR | Groups IG1/2 (n= 18): Spinal manipulation alone (SM) + PM (PM) 1 visits/wk- 3 wks Dropouts: IG3/4 (n= 18) SM; or SM + PM 2 visits/wk- 3 wks Dropouts: IG5/6: (n= 18) SM; or SM + PM 3 visits/wk- 3 wks Dropouts: IG7/8: (n= 18) SM; or SM + PM 4 visits/wk- 3 wks Dropouts: | Outcomes: Pain: Von Korff Pain Scale (0-100) Results- Immediate post tx: Pain: IG1/2: 37 (29)/ 40 (31) IG3/4: 2 31 (21)/ 37 (22) IG5/6: 21 (12)/ 25 (22) IG7/8: 22 (24)/ 19 (16) Short term: Pain: IG1/2: 46 (27)/ 38 (23) IG3/4: 46 (26)/ 37 (20) IG5/6: 18 (20)/ 29 (18) IG7/8: 50 (25)/ 19 (14) | Outcomes: QoL/ well being: NR Disability: Von Korff Disability Scale (0-100) Immediate post tx: IG1 /2: 27 (29)/ 31 (32) IG3/4: 25 (21)/ 21 (20) IG5/6: 5/6:13 (11)/ 21 (22) IG7/8: 10 (14)/10 (11) Short term: IG1 /2: 30 (21)/ 26 (21) IG3/4: 37 (31)/ 22 (24) IG5/6: 8 (17)/ 21 (14) IG7/8: 39 (30)/ 13 (14) Intermediate: NR Long term: NR Harms: No AE was reported by pts
Herzog (1991)124 Country: Canada Quality score: 5/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 4 wks Final assessments: 4 wks N screened: 120 N randomized: 29 N completed tx: 29 N attended last fu: NR Inclusion: Chronic sacroiliac joint problem, 18-50 yrs, ambulatory Exclusion: Extreme obesity | Mean age (SD/range): 33.5 yrs % of male: 67.5% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: N-S Duration of Pain: Mixed, NR Severity of pain (Grading): NR Co-interventions: NR | IG (n = 16) – Spinal manipulation: Manipulation (sacroiliac); 10 sessions over 4 wks, or until complete recovery Drop outs: B = 8 CG (n = 13) – Back school: stretching and postural EXs; Same as IG Drop outs: NR | Outcomes: Pain: VAS (0-10) Disability: Oswestry Results: Baseline: Pain: NR Disability: NR Immediate post tx: Pain: NR Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: No raw data reported. CG was a better tx modality than the IG according to the clinical measures of rehabilitation. Precisely opposite results were found for the biomechanical measures.
Lalanne, K (2009)125 Country: Quebec Quality score: 1/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: one session Fu duration: imm. Post-tx N screened: 27 N randomized: 27 N completed tx: 27 N attended last fu: 27 Inclusion: 18-60 yrs; constant or recurrent LBP for more than 6 mo Exclusion: spondylolisthesis; axial skeletal inflammation or osteoarthritis; collagenosis; osteoporosis; spinal surgery; neuromuscular disease; lower limb musculoskeletal injuries; malignant tumor; hypertension; infection; or any other non-mechanical condition; radiculopathy; progressive neurological deficit; myelopathy; herniated lumbar disc; and severe pain >7 on VAS. | Mean age (SD): IG = 36.1 (12.3) vs. CG = 43.5 (10.5) yrs % of male: IG = 61.5%, CG = 42.8% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: NS Duration of Pain: Chronic, <1 yr >10 yrs Severity of pain (Grading): Pts with severe pain (VAS > 7) were excluded Co-interventions: EX + education and counseling sessions about pain and stress management- + EMG biofeedback to relax the back during trunk flx task | Groups IG (n = 13)– Lumbar spine manipulation: spinous pull method - applied to middle lumbar segments; 1 manipulation Drop outs: 0 CG (n = 14) – Control: (no manipulation-side lying posture) same position as IG lying on left side for 10 sec Drop outs: 0 | Outcome instruments: Pain: VAS (1-100) Results: Baseline: Pain: IG = 26.9 (21.8), CG = 23.3 (21.8) Immediate post tx: Pain: IG = 24.9 (22.3), CG = 30.1 (26.9) Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Mean angles of flextion relaxation phenomenon/EMG activity (data not shown) Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR
Mohseni-Bandpei, M (2006)126 Country: UK Quality score: 2/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: not clear, 3-6 wks? Final assessments: immediately post tx N screened: 233 N randomized: 120 N completed tx: 107 N attended last fu: NR Inclusion: Patients with CLBP, 18-55 yrs with pain in LB between L1 and L5 and the sacroiliac joints; had LBP > 3 mo, signs and symptoms interpreted to be referred from the lumbar spine and not other organs, good self-reported general health Exclusion: History of prior tx including manipulation, chiro, osteopathy, ultrasound; receiving disability benefit as a result of LBP; underlying disease | Mean age (SD/range): IG = 34.8 (10.6) vs. CG = 37.2 (10.2) yrs % of male: IG = 39%, CG = 43% Racial composition: NR Work status: NR Other socio-demographics: Smokers: 50%; Meds: 50%; Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: N-S Duration of Pain: Chronic, IG = 35.9 (48.3); CG = 50.8 (62.9) Severity of pain (Grading): NR Co-interventions:1 pt dropped out during tx due to co-intervention | Groups IG (n = 60)– SM + Exercise, HV thrust applied on lumbar spine and sacro-iliac joint after end of range; 1^st^ session 40 min, rest 20 min Drop outs: A = 5, B = 8 CG (n = 60) – Ultrasound + Exercise: Frequency of 1 MHz used; 6 sessions, 1-2 times/wk | Outcome instruments: Pain: VAS (0-100) Disability: Oswestry Disability Index (%) Data shown are mean within group differences from baseline: Results: Immediate post tx: Pain: 41.6 vs. 25. 1, p = 0.012 Disability: 17.9 vs. 10.1 Short term: NR Intermediate: Pain: 37.9 vs. 22.8 Disability: 16.7 vs. 11.5 Long term: NR | Outcome instruments: QoL/ well being: NR Results: mean within group differences from baseline: Immediate post tx: lumbar flx (mm): 16.0 vs. 6 Lumbar extenstion (mm): 9.0 vs. 5.0 Short term: NR Intermediate: NR Long term: NR Harms: one Pt droped out due to TP, no indication of group allocation
Postacchini (1988)115 Country: Italy Quality score: 6/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: Varied, see intervention detail Final assessments: 1 yr N screened: 459 N randomized: 398 N completed tx: 375 N attended last fu: NR Inclusion: Pts presenting at two LB clinics, 17-58 yrs Exclusion: BP related to neo-plastic or infectious diseases of the spine, pregnancy, nursing women, pts with serious general diseases, psychiatric disturbances, medico-legal litigation | Mean age (SD/range): NR % of male: 50.5% total Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: N-S Duration of Pain: Mixed, NR Severity of pain (Grading): NR Co-interventions: NR | IG1 (n = 87) – Manipulation: standard technique; 7 tx for 1^st^ wk, then 2 tx for up to 6 wks IG2 (n = 81) – Drug therapy: Diclophenac “full dose”; 10-20 ds IG3 (n = 78) – Physiotherapy: massage, electrotherapy, infrared, etc.; 7 tx/wk for up to 3 wks CG1 (n = 29) – Bed rest: NR; 15-24 hrs for up to 8 ds CG2 (n = 50) – Back school: NR; 4 sessions in 1 wk CG3 (n = 73) – Placebo gel: NR; 2 tx/ds for up to 2 wks Drop outs: Total lost to follow-up = 23 | Outcomes: Data reported in graphs for subgroups (data not shown) Results: Immediate post tx: Disability: IG = 9.1 (5.3), CG = 3.9 (4.3) Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: no significant differences in outcomes of pain and disability at long term fu between groups.
Rasmussen J (2008)127 Country: Denmark Quality score: 6/13 Initial of reviewer: SG | Trial Design RCT Tx duration: NR Final assessments: 2 wks, 4 wks, and 1 yr N screened: 97 N randomized: 72 N completed tx: 72 N attended last fu: NR Inclusion: 18-60 yrs; LBP more than 3 mo Exclusion: ongoing insurance claim; unsettled social pension claim; LBP caused by major accident; pain ext below knee; excessive distribution of pain according to a pain drawing; neurological diseases including known disc herniation; significant medical diseases including cancer; inflammation | Mean age (SD/range): IG = 38 vs. CG = 42 yrs % of male: IG = 51 %, CG = 43% Racial composition: NR Work status: 7% Unemployed Other socio-demographics: 58% Married; 35% Smokers Co morbidities: Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: NR, % with radiating pain: IG = 54, CG = 78 Duration of Pain: Chronic, [median (quartiles) IG = 17 (6-47) mo; CG = 8 (4-41) mo Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 35)– Extension EX + manipulation: 2 simple ext EXs; high velocity, low amplitude thrust at the level of reduced movement, called dysfunction; 3-5 times/EX, repeated 4-6 times, at least once/hr Drop outs: Total for both groups: D=16 CG (n = 37) – Extension EX: 2 simple ext EXs; same as IG | Outcomes: Pain: VAS (0-10) Results: Baseline: Pain: IG = 5 (0.76), CG = 5 (0.76) Immediate post tx: Pain: --- Short term: at 4 wks VAS: IG = 3 (0.76), CG = 3 (0.76) Intermediate: NR Long term: at 1 yr VAS: IG = 2 (0.51), CG = 2 (0.51) | Outcome instruments: QoL/ well being: NR Degree of reduced mobility of most affected segments Results: Immediate post tx: Strong: 1 (3%) vs. 6 (17%) Medium: 10 (29%) vs. 6 (17%) Light: 24 (69%) vs. 23 (66%) Short term: NR Intermediate: NR Long term: NR Harms: 4 pts in IG repoted worsening of pain after 4 wks vs. 3 in CG Similar in 3 mos and 1 yr. No pts was hospitalized during fu perioe due to LBP or disc herniation
Triano JJ (1995)128 Country: US Quality score: 6/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 4 wks Final assessments: 3 mos N screened: 1267 N randomized: 209 N completed tx: NR N attended last fu: NR Inclusion: Pts aged ≥ 18 yrs with mechanic CLBP (pain > 12 mo between L1 and L5 including sacroiliac joints) experiencing palpatory tenderness Exclusion: Neuropathy, systemic disease affecting musculoskeletal system, severe osteoporosis, fracture, spinal pathology, receiving other tx for back pain | Mean age (SD/range): 41.6 (14.7) yrs (total) % of male: 54% total Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Mechanical Duration of Pain: Chronic, NR Severity of pain (Grading): NR Co-interventions: NR | IG1 (n = NR) – SM (HVLA): applied to lumbar and pelvic site(s) pts in laterally posture on table, free leg flexed at knee and pelvis to cause relative flx of lumbar spine; daily 2 wks Drop outs: C = 7 IG2 (n = NR) – HVLF mimic: one side only to avoid accumulation effect; pt placed on a table center with legs bent bilaterally; as IG1 Drop outs: C = 14 CG (n = NR) – BEP: no physical contact or EXs,included attractive color graphics coupled with common anatomic and biomechanical information on spine function and hygiene; as IG1 Drop outs: C = 18 | Outcomes: Pain: VAS Disability: Oswestry Results- Immediate post tx: Pain: IG1 = 13.9 (15.3), IG2 = 19.8 (18.3), CG = 19.6 (17.6) Disability: IG1 = 9.5 (6.3), IG2 = 15.5 (10.8), CG = 12.3 (8.4) Immediately post tx with withdrawals: VAS: IG = 13.3 (15.9), IG2 = 21.7 (24.4), CG = 15.1 (19.4) Oswestry: IG1 = 10.6 (11.7), IG2 = 14 (11.7), CG = 11.4 (10.3) | Outcome instruments: QoL/ well being: NR Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR
Waagen, G (1986)129 Country: Iowa, US Quality score: 5/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 2 wks Fu duration: 2 wks N screened: NR N randomized: 29 N completed tx: 29 N attended last fu: 17 Inclusion: chief complaint of LBP; no experience with chiro Exclusion: pregnancy, malingering, workmen's compensation for back problem, not ambulatory, obesity, radiographic evidence of osseous fractures, osteoporosis or spondylolisthesis, BP result of visceral disorder, positive indication of disk herniation, severe concurrent infectious or other systemic disease process, neurologic deficits indicated by leg pain or numbness or weakness | Mean age (SD/range): IG = 25.2 vs. CG = 24.3 yrs % of male: IG = 54.5%, CG = 38.9% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Non-specified Duration of Pain: Chronic, IG = 2.5 yrs, CG = 2.8 yrs Severity of pain (Grading): pre-trial pain level: IG = 3.7, CG = 4.6 Co-interventions: NR | Groups IG (n = 11)– Adjustment: spinal adjustive therapy only, full-spine adjustments administered to each pt to Sally correct all chiropractic lesions found by clinician; 2-3 tx/wk for 2 wks Drop outs: B = 2 CG (n = 18) – Sham adjustment: using minimal force for generalized manipulation; simulated by applying gentle pressure over both posterior superior iliac spines such that lumbar section fell; tx concludes with paraspinal soft tissue massage; same as IG Drop outs: B = 8 | Outcomes: Pain: 10 cm VAS decrease after tx and at 2 wks post tx Disability: NR Results- Immediate post tx: Pain-mean change: IG = 1.3, CG = 0.7 Short term: Pain-mean change: IG = 2.3, CG = 0.6 | Outcome instruments: QoL/ well being: Global index change from baseline: IG = 1.71, CG = -2.08 Other: Leg raising test: D-mean change: IG = 6 (8.65), CG = -13.5 (10.3) IG = 6 (6.2), CG = -15 (5.8); Short term: NR Harms: NR

Table 1.13 Low Back Pain – Manipulation – Mixed - Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Mathews W (1988)130 Country: United Kingdom Quality score: 2/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 2-3 wks Final assessments: post-tx N screened: 895 N randomized: 282 N completed tx: NR N attended last fu: NR Inclusion: 18-60 yrs of age; presenting episode of pain of less than 3 mo Exclusion: NR | Mean age (SD/range): NR % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Specifically defined syndromes of LBP alone (lumbago) and LBP with pain in the leg (sciatica) Duration of Pain: Acute, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 158) – Rotational Manipulation: 2 trials, pain on forward flx but ext was pain free, direct vertical pressure was applied first. Leg of more painful side was lifted and used to rotate the pelvis over, and away from that side, body weight was utilized to apply over-pressure using the length of the leg as a lever, short or long, applying the force through the pt's buttock; unclear Drop outs: NR CG (n = 134) – Control: 2 trials, Infrared lamp over the most painful area of the LB; 15 min/tx, 3 tx/wk for 2-3 wks Drop outs: NR | Outcomes: Pain: VAS (n “recovered”) Disability: Oswestry Disability Index (data shown in graphs. Numeric values could not be extracted and are not shown in this table) Results: Immediate post tx: Pain: IG = 116, CG = 73; P = 0.05 Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: back school therapy was a better tx modality than the SM according to the clinical measures of rehabilitation.
Zhang, W (2008)131 Country: China Quality score: 4/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 30 ds Final assessments: post-tx N screened: NR N randomized: 11128 N completed tx: 11088 N attended last fu: 11088 Inclusion: diagnosed using Chinese Medical Diagnostic and therapeutic Effective Standard, diagnosed using CT or MRT, sign on consent form Exclusion: pregnant, breast feeding, Lumbar intervertebral disc hemiation plus Mawei nerve synthesize, lumbar tumor or tubercal, headache or heart pain etc. high blood pressure, heart disease, the other serious disease related to organ or system, and people with mental health issues | Mean age (SD/range): NR % of male: NR Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc/joint disease Duration of Pain: Acute, Sub-acute, chronic; IG = 2 ds-30 yrs, CG = 1 d-26 yrs Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 5760)– Manipulative reduction + lumbar traction + various physiotherapies: 25-30 kg traction, 20-30 min/tx, microwave trt-12-15 w, 20 min/tx, middle frequency trt, Chinese medicine fumigate ; 1 tx/d, 10 tx/course, 3 courses Drop outs: B = 23 CG (n = 5368) – lumbar traction +various physiotherapies: 25-30kg traction, 20-30 min/tx, microwave trt: 12-15 w, 20 min/tx middle frequency trt Chinese medicine fumigate; same as IG Drop outs: B = 17 | Outcomes: Pain: VAS Results: Baseline: Pain: IG = 7.82 (2.25), CG = 8.1 (1.81) Immediate post tx: Pain-mean change: IG = 2.13 (1.46), CG = 4.65 (2.14) Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: well being, instrument NR (% improved) Results: Immediate post tx: IG = 98.6%, CG = 96.4% Short term: NR Intermediate: NR Long term: NR Harms: NR

Table 1.14 Low Back Pain - Manipulation - Mixed - Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Childs JD (2004)132 Country: US Quality score: 8/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 4 wks Final assessments: 6 mos N screened: 543 N randomized: 131 N completed tx: 131 N attended last fu: NR Inclusion: LBP pts aged 18-60 yrs with ODQ score ≥ 30% Exclusion: serious spinal condition (tumor, compression fracture, or infection), nerve root compression, positive straight leg increase < 45 degrees of diminished reflexes, sensation, or lower extremity strength, pregnant, previous surgery to the lumbar spine or buttock | Mean age: 34 yrs % of male: IG = 57%, CG = 59% Racial composition: NR Work status: NR Other socio-demographics: Smokers: IG = 17.1 %, CG = 29.5% Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Symptoms distal to the knee: IG = 25.7%, CG = 21.3% Duration of Pain: Acute and Sub-acute, IG = 22 ds; CG = 30 ds Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 70) – SM + Exercise: During 1st two PT sessions, pts received high-velocity thrust SM and range-of-motion EX only; the first, PTst performed manipulation by using the technique reported by Flynn et al.; 4 wks Drop outs: D = 18 CG (n = 61) – Exercise: low-stress aerobic and lumbar spine strengthening program which targeted the trunk musculature identified as important stabilizer of the spine in the literature; 4 wks Drop outs: D = 21 | Outcome instruments: Pain: Disability: ODQ Results: Baseline: Disability: IG = 41.4 (10.1); CG = 40.9 (10.8) Immediate post tx: Disability: NR Short term: 1 vs. 2 10.1-P = 0.001 Intermediate: NR Long term: NR Data for short term fu collected for IG, n = 52 CG, n - = 40 | Outcome instruments: QoL/ well being: NR % pts with Med use in the last wk- Short term (6 mos fu): 36.5% vs. 60.0% Missed time at work in last 6 wks due to BP: 9.6% vs. 25% Seeking tx for BP: 11.5% vs. 42.5% Intermediate: NR Long term: NR Harms: drop out not due to AE Summary: ODQ scores of SM was greater if performed by practitioners with < 3 yrs of experience compared to that for those with ≥3 yrs of experience
Cherkin D (2008)133 Country: Ottawa, Canada Quality score: 5/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 1 mo Final assessments: 3 mos N screened: 3800 N randomized: 321 N completed tx: 307 N attended last fu: 298 Inclusion: 20-64 yrs old who saw their primary care physician for LBP and who still had pain seven ds later Exclusion: NR | Mean age: 40 yrs % of male: 52.6% total Racial composition: NR Work status: 88% Employed Other socio-demographics: 15.6% Smokers Co morbidities: NR Prior episode of pain if acute: 56% with .2 episodes Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Unknown, 6 wks Severity of pain (Grading): NR Co-interventions: NR | Groups IG1 (n = 133)– Physical therapy: relies on pt-generated forces and emphasizes self-care; up to 9 visits over 1 mo Drop outs: A = 4,B = 0 IG2 (n = 122)– Chiro manipulation: a short-lever, high-velocity thrust directed Sally at a “manipulable lesion”; same as IG1 Drop outs: A = 3,B=0 CG (n = 66) – Educational booklet: discussed causes of back pain, prognosis, appropriate use if imaging studies and specialists, and activities for promoting recovery and preventing recurrences; initial consultation only Drop outs: A = 1,B=5 | Outcomes: Pain: symptom bothersomeness (VAS) Disability: RDQ Results: Immediate post tx: Pain: 2.3 (2.61), vs. 1.9 (1.94), CG = 3.1 (2.96) Disability: IG1 = 4.1 (4.64), IG2 = 3.7 (4.43), CG = 4.9 (4.35) Short term: Pain: IG1 = 2.7 (2.76), IG2 = 2 (2.22), CG = 3.2 (3.2) RDQ: IG1 = 4.1 (4.97), IG2 = 3.1 (4.16), CG = 4.3 (4.86) Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Results: Immediate post tx: Short term: Intermediate: NR Long term: NR Harms: No important AE effects of tx wre reported in any of the groups
Hoehler F (1981)134 Country: US Quality score: 3/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: NR Final assessments: 3 wks post discharge N screened: 1880 N randomized: 95 N completed tx: NR N attended last fu: NR Inclusion: presence of palpatory cues indicating that manipulation might be successful Exclusion: Manipulation contraindicated or alternative tx strongly indicated; pregnancy; previous experience with manipulation; disability income; pending litigation; previous back surgery; obesity; drug or alcohol abuse; pain not treatable by manipulation of lumbosacral area. | Mean age (SD/range): IG = 30.1 (8.4) vs. CG = 32.1 (9.8) yrs % of male: 59% total Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: 50% Acute, 23% Chronic Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 56)– Manipulation: rotal manipulations of the lumbosacral spine; # of tx varied Drop outs: NR CG (n = 39) – Soft-tissue massage: soft-tissue massage of the lumbosacral areas, with the rotal thrust omitted; same as IG Drop outs: NR | Outcome instruments: Pain: Improvement in pain (see summary) Disability: NA Results: Immediate post tx: Pain: --- Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Results Immediate post tx: Pts reporting tx as effective: 88% vs. 86% Improvement in SLR (to pain): 7.8 (7.4) vs. 8.6 (8.4) Short term (3 wks post discharge): Pts reporting improvement in amount of pain from baseline – IG = 88%, CG = 68% Intermediate: NR Long term: NR Harms: NR
Bronfort, G (1989)135 Country: Denmark Quality score: 2/13 Initial of reviewer: SG | Trial Design- RCT Tx duration: 1 mo Final assessments: immediately post tx N screened: 21 N randomized: 19 N completed tx: 19 N attended last fu: NR Inclusion: Native to chiropractic and between 18-70 yrs of age. Primarily suffering from LBP of various durations with or without radiating pain to one or both lower extremities Exclusion: LBP due to destructive, metabolic and inflammatory disease, organic referred pain syndromes, vascular and circulatory diseases of the lower extremities, psychological disturbances, nerve root or spinal cord compression syndromes warranting surgical intervention, essentially weakened health. | Mean age (SD/range): IG = 36 (4) vs. CG = 39 (3.9) yrs % of male: IG = 20%, CG = 78% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: IG = 60, CG = 22 (with more than 3 episodes, N-S if acute) Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 10)– Chiropractic: S manipulative procedures carried out with LAHV aimed at selected dysfunctional articulations involving all sections of spine and pelvis as detected by motion palpation, instructions given on how to minimize risk of future LBP episodes; 1 mo Drop outs: A = 2 CG (n = 9) – Medical: Mostly analgesic Med prescription, local analgesic-anaesthestic injections, bedrest and or PTincluding ultrasound, diathermy & ergonomic advice; 1 mo Drop outs: NR | Outcome instruments: Pain: % of pts improved Disability: NR Results: Ptient’s assessment of improvement- % with no pain: Immediate post tx: 20% vs. 22% Short term: 20% vs. 11% Intermediate: 50% vs. 11% Long term: NR | Outcome instruments: QoL/ well being: NR Patient’s assessment of pain according to gender- % with no pain at 6 mos: male 40% vs. female 20% Intermediate fu: Use of analgesics during 6 mos (%): 10% vs. 33% Unable to work at 6 monhts: 10% vs. 11% Harms: worse pain compared to baeline after tx 10% vs. 11 %; short term & intermediate fu 0 in both groups; tx for LBP.
Rupert R (1985)136 Country: Egypt Quality score: 2/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: unspecified Final assessments: immediately post tx N screened: 145 N randomized: 145 N completed tx: NR N attended last fu: NR Inclusion: 18-68 coming to three hospitals for low-back pain and/or restriction in lumbar ROM. Exclusion: Pts familiar with manipulation; spinal cord involvement, osseous pathology, tumors, bleeding disorders, acute inflammatory joint diseases, acute or progressive neurological defecit, chronic systemic disease, pain referred from visceral pathology, and advanced pregnancy | Mean age (SD/range): NR % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: N-S Duration of Pain: Mixed, NR Severity of pain (Grading): NR Co-interventions: NR | IG (n = 49) – Chiropractic adjustment: Specific short-lever manipulation using spinous processes or mamillary bodies as lever arms; 3 tx/wk, duration of trial unspecified Drop outs: NR CG1 (n = 46) – Sham manipulation: touching and palpitating the pt on the adjusting table in the same tx setting as IG. CG1 received a non-therapeutic massage to a site unrelated to the area of pain; 3tx/wk Drop outs: NR CG2 (n = 50) – Drugs and bed rest; 3 tx/wk Drop outs: NR | Outcomes: Pain: VAS - % LBP improvement (data shown in graphs-not extracted) Results: Immediate post tx: Pain: IG = 47%, CG1 = 19%, CG2 = -40% Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: Trial only reports preliminary data, does not specify the duration of the trial and # of txs- pts uncder 40 yrs of age noted more immediate pain relief than those over 40.
Hoiriis, K (1999)137 Country: NR Quality score: 0/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: up to 6 mos Final assessments: imm.post tx N screened: 800 N randomized: 26 N completed tx: NR N attended last fu: NR Inclusion: LBP of greater than 2 mo Exclusion: presence of serious disease, cervical complaint, or postsurgical low back syndrome | Mean age (SD/range): NR % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Sub-acute, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG1 (n = )– Cervical Adjustments: NR; pts adjusted up to 6 mo Drop outs: NR IG2 (n = ) – Full Spine adjustments: NR; same as IG1 Drop outs: NR CG (n = ) – Combination of both techniques; same as IG1 Drop outs: NR | Outcomes: -report of significant improvement from initial values Pain: VAS-Only results for all groups together are given (Baseline=4.04, follow-up=1.57) Disability: Oswestry Disability Q-Only results for all groups together are given Results: Immediate post tx: Pain: ---- Disability: --- Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR
Herzog (1991)124 Country: Canada Quality score: 6/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 4 wks Final assessments: immediately post tx N screened: 120 N randomized: 29 N completed tx: 29 N attended last fu: NR Inclusion: Chronic sacroiliac joint problem, 18-50 yrs, ambulatory Exclusion: Extreme obesity | Mean age (SD/range): 33.5 yrs % of male: 67.5% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: N-S Duration of Pain: Mixed, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 16) – Spinal manipulation: Manipulation (sacroiliac); 10 sessions over 4 wks, or until complete recovery Drop outs: B = 8 CG (n = 13) – Back school: stretching and postural EXs; Same as IG Drop outs: NR | Outcomes: Pain: VAS (0-10) Disability: Oswestry Results: Baseline: Pain: NR Disability: NR Immediate post tx: Pain: NR Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: No raw data reported. CG was a better tx modality than the IG according to the clinical measures of rehabilitation. Precisely opposite results were found for the biomechanical measures.
Hondras, M (2009) 138 Country: USA Quality score: 11/13 Initial of reviewer: ST | Trial Design: RCT Tx duration: max 12 visits Final assessments: 18 wks post tx N screened: 1849 N randomized: 240 N completed tx: 225 N attended last fu: NR Inclusion: Age at least 55 yrs, presented with nonspecific LBP of at least 4 weeks duration and met the diagnostic classification of 1, 2, or 3 according to the Quebec Task Force on Spinal Disorders. Exclusion: LBP with: radiculopathy/neurological signs; comorbidities or general poor health that could complicate the prognosis; major clinical depression; bone/joint pathology that contraindicated SM; current/pending litigation; pacemaker; receiving disability for any condition; received SM within the past month; unwilling to postpone the use of MT for LBP except for those provided in the study; unable to comprehend English. | Age: Mean (yrs) IG1 = 63.8 (7.6) IG2 = 62.3 (6.1) CG = 63.0 (6.0) % male: IG1 = 55.2%; IG2 = 55.8%; CG = 59.2% Racial composition: White: IG1 = 95.8%, IG2 = 95.8%, CG = 98%; Hispanic: IG1 = 2.1%; , IG2 = 2.1%; , CG = 6.1% Work status: Full-time: IG1 = 34.4%, IG2 = 40%, CG = 34.7%; Comorbidities: NR Prior episode of pain if acute: NR Prior surgery related to current complaint: NR | Cause of Pain: NR Duration of Pain: Mean (SD): IG1= 11.9 y (13.4), IG#2 = 15.1 y (16.7), CG = 9.6 y (11.1) Severity of pain - Avg low back pain during past week 0-100mm: IG#1 = 42.1 (23.6), IG#2 = 42.5 (25.2), CG = 42.4 (24.5) Conterventions: NR | Groups IG1 (n = 96) – High-velocity low amplitude SM; max 12 visits, not to exceed 3x/wk for 1st 2 wks, 2x/wk for wks 3 & 4, 1x/wk for wks 5 & 6. 30 min home exercise instruction. Drop outs: 2 IG2 (n = 95) – Low-velocity variable amplitude SM; max 12 visits, not to exceed 3x/wk for 1st 2 wks, 2x/wk for wks 3 & 4, 1x/wk for wks 5 & 6. 30 min home exercise instruction. Drop outs: 4 CG (n = 49)-Minimal conservative medical care; 3x over 6 wks Additional visits as necessary. 30 min home exercise instruction. Drop outs: 9 | Outcome instruments: Pain: VAS (0-100mm) No Pain - Worst Pain Disability: RMD (0-24); FABQ physical subscale (0-24); SF-36 physical function subscale (0-100) Results: Baseline: Pain: QTF 1 – IG1 = 66.7%, IG2 = 60%, CG = 61.2%; Disability: RMD – IG1 = 6.5 (4.1), IG2 = 6.6 (4.6), CG = 5.7 (4.0); Immediate post tx -Mean chg from baseline (range): Pain: No significant results Disability: RMD - IG1 = 2.7 (2.0, 3.3), IG2 = 2.9 (2.2, 3.6), CG = 1.6 (0.5, 2.8); Short term: NR Intermediate: NR | Outcome instruments: QoL/ well being: NA Results: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: No serious adverse events. Summary Biomechanically distinct forms of SM did not lead to different outcomes in older LBP patients and both SM procedures were associated with small yet clinically important changes in functional status by the end of treatment for this relatively health older population.

Table 1.15 Low Back Pain - Manipulation - Unknown - Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Dai, DC (2006)139 Country: China Quality score: 3/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 5 wks Final assessments: post-tx N screened: 99 N randomized: 99 N completed tx: 99 N attended last fu: 99 Inclusion: Lumbar stability of degenerative spondylolishesis Exclusion: History of lumbar surgery, Severe lumbar trauma, Bone TB and tumor, Pts with central nervous symptoms,Serious cardiovascular and cerebrovascular disease, Psychiatric pts | Mean age (SD/range): IG = 58.86 (7.24) vs. CG = 57.37 (7.43) yrs % of male: IG = 22%, CG = 24.5% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Spondylolysis with spondylolisthesis Duration of Pain: Cannot tell Severity of pain (Grading): Co-interventions: So ft-tissue manipulation | Groups IG (n = 50)– Spinal fine adjusting manipulation: NR; 20 min/ tx, 2 tx/ wk for 5 wks Drop outs: 0 CG (n = 49) – Flexing hip and knee manipulation: NR; same as IG Drop outs: 0 | Outcomes: Pain: Local STD of integrated score of symptoms and function Disability: x-ray changes of lumbar spine Results-Baseline: Pain: IG=7.62 (2.22), CG =7.92 (2.06) Disability: --- Immediate post tx: Pain: IG = 3.38 (1.14), CG = 3.97 (1.76) Disability: ---- Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Excellent rate of tx: Immediate post tx: 60% vs. 36.7% Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: lumbar lordosis, lumbosacral angle in IG appeared significant changes after spine fine adjusting compared to baseline.

Table 1.16 Low Back Pain – Manipulation - Unknown - Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Shearar K (2004)140 Abstract Country: South Africa Quality score: 1/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 2 wks Final assessments: imm.post tx N screened: 60 N randomized: 60 N completed tx: 60 N attended last fu: 60 Inclusion: 18 - 59 ; diagnosed with sacroiliac joint syndrome Exclusion: NR | Mean age (SD/range): NR % of male: approx. 50% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Sacroiliac joint syndrome Duration of Pain: Unknown, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 30)– HVLA chiropractic adjustments: National-Diversified Technique; 4 tx over 2 wks Drop outs: NR CG (n = 30) – Mechanical force, manually assisted chiropractic adjustments: using an Activator Adjusting Instrument; same as IG Drop outs: NR | Outcome instruments: Pain: NRS-101-mean values only Disability: Revised ODQ Results: Baseline: Pain: IG = 49.1, CG = 48.9 Disability: IG = 37.4, CG = 36.6 Immediate post tx: Pain: IG = 23.4, CG = 22.5 Disability: IG = 18.5, CG = 15.1 Short term: Intermediate: Long term: | Outcome instruments: QoL/ well being: NR Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR

Table 1.17 Low Back Pain – Mobilization – Acute/Sub-acute-non Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Hadler NM (1987)109 Country: US Quality score: 7/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: NR Final assessments: immediately post tx N screened: 57 N randomized: 54 N completed tx: NR N attended last fu: NR Inclusion: Pts aged 18-40 yrs with acute LBP (≤ 1 mo), no other episode of back pain in previous 6 mo, not work-related pain, no previous surgery Exclusion: NR | Mean age (SD/range): NR % of male: 48% total Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: Non-S Duration of Pain: Acute ≤ 2 wks: n = 13 Severity of pain (Grading): NR Co-interventions: NR | IG (n = 28) – Mobilization: Pt was positioned first on the right and then on the left side; the operator grasped both knees with one arm while pressing down on the on the pts’ lower spine with the opposite hand; then the subjects legs were gently flexed on the hips twice; NR Drop outs: NR CG (n = 26) – Manipulation: HV thrust was applied to the lower spine while stabilizing the thorax; NR Drop outs: NR | Outcomes: Disability: RMDQ Results: Baseline: Disability: NR Immediate post tx: Disability: IG = 9.1 (5.3), CG = 3.9 (4.3) Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: SM was more effective than Mob at reducing disability score in the first wk of tx (time and tx interaction significant p < 0.04) for those with duration of pain of 2-4 wks
Hanrahan, S (2005)141 Country: U.S. Quality score: 2/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: NR Final assessments: immediately post tx N screened: 19 N randomized: 19 N completed tx: 19 N attended last fu: NR Inclusion: All male collegiate athletes with acute LBP for less than 48 hrs. Mechanical LBP, not radicular. Prior tx of lumbar spine not excluded Exclusion: Any conditions (e.g. Neurologic deficit or suspected disk herniation) for which joint Mob techniques were contraindicated. Any radicular, disk, or fracture involvement | Mean age (SD/range): 20.3 yrs % of male: 100 Racial composition: NR Work status: NR Other socio-demographics: Height: 185.4 cm avg; Weight: 92 kg avg Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Acute Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 9)– Experimental: standard tx of cryotherapy and stretching, grade 1 and 2 joint Mobs administered at the lumbar spine; 30 sec each, 6 repetitions Drop outs: A=0, B=0 CG (n = 10) – Control: standard tx protocol of cryotherapy and stretching, placed in prone position of comfort during joint Mobs; NR Drop outs: NR | Outcome instruments: Pain: MPQ: no numeric data provided Disability: NA Results: Immediate post tx: Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Muscle force: data not shown Results: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: Overall pain decreased for all over time. MPQ (P = 0.001). Pain decreased for the sensory pain subscale (P = 0.000) and difference was noted between groups and tests (P = 0.048).

Table 1.18 Low Back Pain – Mobilization – Acute/Sub-acute Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Wreje U (1992)142 Country: Sweden Quality score: 4/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 3 wks Final assessments: immediately post tx N screened: 46 N randomized: 39 N completed tx: 32 N attended last fu: NR Inclusion: LBP due to pelvic joint dysfunction (positive test results on the following: asymmetry of the pelvis, movement, and provoked pain) Exclusion: Pregnancy, pain duration > 3 mo, malignancy, neurological disease, lumbar spine pathology | Mean age (SD/range): IG = 31.9 vs. CG = 31.4 yrs % of male: 0 Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: Pelvic joint dysfunction Duration of Pain: Acute, NR Severity of pain (Grading): NR Co-interventions:None | Groups IG (n = 18) – SM: MET and segmental Mob by Kubis, based on pts clinical picture, techniques were combined with stretching of the paracoccygeal ligaments per rectum by putting little pressure on coccyx in dorsal direction; 3 wks Drop outs: n =7(total) CG (n = 21) – Sham-SM: manual transverse frictions on the gluteus medius muscles for three minutes; as IG Drop outs: | Outcome instruments: Pain: VAS [no numerical data] Disability: NA Results: Immediate post tx: Pain: --- Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: The use of analgesics was higher in the CG compared to IG (p < 0.05) over 3 wks; there was no between group difference in pain

Table 1.19 Low Back Pain – Mobilization – Chronic-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Timm (1994)143 Country: US Quality score: 4/13 Initial of reviewer: SG | Trial Design-RCT- Tx duration: 8 wks Final assessments: Post-tx N screened: NR N randomized: 250 N completed tx: 250 N attended last fu: 250 Inclusion: lumbar-related pain and associated symptomatology for at least 6 mo prior to the period of study following a single-level lumbar laminectomy of the L5 segment performed at least 1 yr before the start of the experiment; intermittent or constant pain in one of the lower extremities but not below the level of the knee Exclusion: NR | Mean age:41 – 45 yrs % of male: 72.8 Racial composition: NR Work status: 100% employed in automotive industry Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: 50 | Cause of Pain: Post laminectomy Duration of Pain: Chronic, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 50) – Joint manipulation: Large amplitude, low velocity Maitland; 3 tx/wk for 8 wks Drop outs: None CG1 (n = 50) – Physiotherapy: hot packs, ultrasound, TENS; Same as IG Drop outs: None CG2 (n = 50) – Low-tech McKenzie EXs: NR; As IG Drop outs: None CG3 (n = 50) – High-tech Cybex EXs: NR; Same as IG Drop outs: None CG4 (n = 50) – No Tx Drop outs: None | Outcomes: Disability: Oswestry; Results- Immediate post tx: Disability: IG = 5.57 (2.38), CG1 = 2.55 (1.03), CG2 = 5.69 (3.1), CG3 = 4.84 (2.67), CG4 = 2.19 (1.54); Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Other: modified Schober (ROM) (cm) Results-mean (SD): Immediate post tx: IG = 6.46 (2.17), CG1 = 6.31 (1.52), CG2 = 8.81 (2.36), CG3 = 9.07 (2.61), CG4 = 6.24 (1.47) Short term: NR Intermediate: NR Long term: NR Harms: NR Note: atuthors concluded that the low tech EX produced longer pain relief and was also most cost-effective.

Table 1.20 Low Back Pain – Mobilization – Chronic-Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Ritvanen T (2007)144 Country: Finland Quality score: 5/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 2 mos Final assessments: 3 mos N screened: 150 N randomized: 61 N completed tx: 61 N attended last fu: 54 Inclusion: Pts with CLBP aged 20-60 yrs who had restricted functioning Exclusion: severe neurologic, metabolic, or CVD , back surgery, mental disease, major structural abnormality, pregnancy | Mean age (SD/range): IG = 40.7 (4.75) vs. CG = 41.5 (5.95) yrs % of male: IG = 54.5%; CG = 57.1% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: N-S Duration of Pain: Chronic, IG = 7 yrs (7); CG = 11 yrs (8) Severity of pain (Grading): NR Co-interventions:Pai nkillers | Groups IG (n = 33) – TBS: based on manual whole body tx; tx starts from toes and feet up to the hands and head mobilizing tissues and malocclusions; 5 tx with 2 wk intervals over 2 mo Drop outs: C = 2 CG (n = 28) – PT: Included massage, therapeutic stretching, trunk stabilization EX, EX therapy; same as IG Drop outs: C = 5 | Outcomes: Pain: VAS Disability: ODQ Results: Baseline: Pain: IG = 40 (4), CG = 41 (4) Disability: IG = 18 (2), CG = 21 (2) Immediate post tx: Pain: NR Disability: NR Short term: VAS: IG = 23 (5), CG = 28 (4) ODQ: IG = 12 (2), CG = 17 (2) Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Finger to floor distance (cm); lateral bending (right and left)-cm. Results: Immediate post tx: finger to floor distance: 5.4 (2.2) vs. 6.3 (1.9) Right lateral bending: 17.1 (0.6) vs. 17.1 (0.7) Left lateral bending: 17.4 (0.7) vs. 16.5 (0.8) Short term: NR Intermediate: NR Long term: NR Harms: NR
Cote P (1994)121 Country: Canada Quality score: 4/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: one session Final assessments: post-tx N screened: NR N randomized: 30 N completed tx: 30 N attended last fu: 30 Inclusion: Pts with mechanic CLBP > 2 mo Exclusion: seronegative spondyloarthropathy or rheumatoid arthritis, lumbar radiculopathy, hip pathology, abdominal/pelvic organ pathology, pregnancy, current use of muscle relaxants or anti-inflammatory drugs | Mean age (SD/range): 31 (7.15) yrs total % of male: IG = 37.5%, CG = 71.4% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Mechanical Duration of Pain: Chronic, 74 (83.3) mo (total) Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 16) – Mobilization: side-lying position, a counter-rot force was created at the lumbo-sacral junction or sacroiliac joints; joint taken to its limit of passive motion and HVLA thrust applied through the joint producing an audible sound; one session Drop outs: 0 CG (n = 14) – Manipulation: a long lever HV thrust applied to the lower spine while stabilizing the thorax in side lying and supine position Drop outs: 0 | Outcomes (instrument used): Pain: PPT: L5 tender point; Sacroiliac (SI) ligament tender point; gluteus tender point (gluteal) Results: Immediate post tx: Pain: L5: IG = 5.6(2.1), CG = 5.1 (3.0); SI: IG = 5.6 (2.1), CG = 5.5 (3.1) Gluteal : IG = 5.6 (2.2), CG = 5.2 (2.7) Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Results: Baseline: NA Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR Summary of results (if provided): The two groups did not differ in mean PPT scores for the three myofascial points (L5 tender point, SI ligament tender point, and gluteus tender point); ANOVA indicated no SS time*tx term interaction (P > 0.267)
Mackawan S (2007)145 Country: Thailand Quality score: 5/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: one session Final assessments: post-tx N screened: NR N randomized: 67 N completed tx: 67 N attended last fu: 67 Inclusion: 20-60 yrs; persistent CLBP (> 12 wks); no evidence of underlying diseases or anatomical abnormalities Exclusion: menstruation; pregnancy; body temp 38.5°C on d of exam.; a history of acute trauma, back surgery, spinal fracture, joint subluxation or instability, inflammatory joint disease muscle disease, malignancy or infection; evidence of neurologic deficits, multiple sclerosis, hemi/para paresis or myelopathy, skin diseases, or infectious diseases | Mean age (SD/range): IG = 38.97 (7.85) vs. CG = 38.57 (7.66) yrs % of male: IG = 34%, CG = 44% Racial composition: NR Work status: Government service = 49%; Private officer = 32.5%; Student= 6%; Business owner = 11.5% Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Chronic, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 35)– Traditional Thai massage(TTM): Deep massage with prolonged pressure (5-10s/point) on the muscles along with passive stretching. Gentle stretching of the joints and muscles relieves tension, enhances flexibility, and induces a deep state of tranquility; one 10 min session Drop outs: NR CG (n = 32) – Joint Mob: passive movement of a spinal segment with and occasionally beyond its active ROM.; as IG Drop outs: NR | Outcomes: Pain: VAS (10 cm); Results: Baseline: Pain: IG = 4.22 (1.98), CG = 4.35 (1.71) Immediate post tx Pain: IG = 2.45 (1.75), CG = 3.39 (1.66) Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Results: NA Baseline: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR
Lopez de, C (2007)146 Country: Spain Quality score: 8/13 Initial of reviewer: SG | Trial Design-RCT- Tx duration: NR Final assessments: immediately post tx N screened: NR N randomized: 100 N completed tx: NR N attended last fu: NR Inclusion: N-S CLBP, aged 18-65 yrs; Exclusion: ongoing insurance claim; unsettled social pension claim; LBP caused by major accident; pain ext below knee; excessive distribution of pain according to a pain drawing; neurological diseases including known disc herniation; significant medical diseases including cancer; inflammation; language problems; suspected noncompliance or planned other tx in the first 4 wks | Mean age (SD/range): NR % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 100) – Mobilization: NR Drop outs: NR CG (n =NR)– No tx: NR Drop outs: NR | Outcomes: Pain: VAS Disability: Roland Morris Results: Baseline: Pain: IG 48.7 vs. CG 49.23 Immediate post tx: Pain: IG 33.40 vs. CG 49.77 Disability: IG 7.89 vs. CG 10.64 Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Other: ROM Immediate post tx: Flexion IG 6.28 vs. CG 5.20 Extension IG 1.80 vs. CG 1.40 Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: IG shoes a significant improtment in pain, lateral beniding, mobility and disability degree.
Hemmila (1997)147 Country: Finland Quality score: 6/13 Initial of reviewer: SG | Trial Design-RCT- Tx duration: 6 wks Final assessments: 6 wks and 6 mos N screened: 147 N randomized: 114 N completed tx: 113 N attended last fu: 113 Inclusion: Back pain between the shoulders and the buttocks Exclusion: retirement, pregnancy, malignancy, rheumatic diseases, severe osteoarthritis, cauda equina syndrome, back operation, or vertebral fracture in the past 6 mos or any condition that would prevent or contraindicate any of the therapies. | Mean age (SD/range): IG = 42 (12); CG1 = 42 (8.9); CG2 = 41 (9.9) yrs % of male: IG = 55.9, CG1 = 55.5, CG2 = 60 Racial composition: Work status: NR Other socio-demographics: 28.3% Smokers Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Mixed, IG = 7 (8.9) yrs; CG1 = 8.5 (10.5) yrs; CG2 = 6.8 (7.2) yrs Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 34) – Bone-setting: NR; 1-2 tx/wk for 6 wks Drop outs: 1 (unclear from which grp or at what point) CG1 (n = 45) – Physiotherapy, mainly manual (no thrusts), thermal, electrotherapy: NR; Same as IG Drop outs: See IG CG2 (n = 35) – Home EXs with individual instruction by PT: NR; Same as IG Drop outs: See IG | Outcomes: Pain: 100 mm VAS ( Disability: NR Results- Immediate post tx: Pain: no significant differences between IG and CG Disability: NR Short term: NR Intermediate: Pain: no numerical mean values reported. Sign difference between IG and CG in favore of IG in VAS Long term: NR | Outcomes: QoL/ well being: NR Other: physical measures, mean change from baseline (mm): at 6 wks Modified Schober; 0.1 vs. 0.8 vs. 2.4 Side Bending: 11.0 vs. 5.4 vs. -2.1 Lumbar Extension: 3.7 vs. 3.6 vs. 3.1 Straight leg raising: 2.4 vs. 1.6 vs. 1.8 Short term: NR Intermediate (6 mos): Modified Schober: 4.0 vs. 2.3 vs. -1.0 Side Bending: 9.3 vs. 3.6 vs. -2.7 Lumbar Extension: 5.4 vs. 6.8 vs. 4.3 Straight leg raising: 2.4 vs. 1.6 vs. 1.8 Long term: NR Harms: NR

Table 1.21 Low Back Pain – Manipulation + Mobilization – Acute/Sub-acute- -Specific Pain - No Trials

Table 1.22 Low Back Pain – Manipulation + Mobilization – Acute/Sub-acute-Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Hancock MJ (2007)148 Country: Australia Quality score: 9/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 4 wks Final assessments: 3 mos N screened: 320 N randomized: 240 N completed tx: 240 N attended last fu: 235 Inclusion: Pts with acute LBP (< 6 wks) in the area between the 12th rib and the buttock crease causing moderate pain and disability Exclusion: present episode of pain not preceded by pain-free period of ≥ 1 mo in which care was not provided, serious spinal pathology, nerve root compromise, NSAIDs use or SM, spinal surgery in the preceding 6 mo, contraindication to NSAIDs and SM | Mean age (yrs) (SD/range): IG1 = 39.5 (15.8), IG2 = 41.1 (15.4) % of male: IG1 = 58%, IG2 = 54% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Acute, NR Severity of pain (Grading): NR Co-interventions: par acetamol 1 g 4 times/d + advise | Groups IG1 (n = 60)– Diclofenac: NSAID; 50 mg twice/d, 4 wks Drop outs: n = 3 IG2 (n = 60) – SM: The algorithm-based approach, Mob or HV thrust aiming to produce motion at the joints of the lumbar spine thoracic spine, sacroiliac joint, pelvis and hip; 2-3 times/wk, 4 wks Drop outs: n = 2 IG3 (n = 60) – Diclofenac + SM + SMo; 4 wks Drop outs: n = 0 CG (n = 60) – Placebo manipulative therapy + placebo diclofenac: NR Drop outs: n = 0 | Outcomes: Pain: NRS (0 – 10); also d to recovery (primary outcome of study) Disability: RMDQ Results- Immediate post tx: Pain: - 2.0 (-0.7 – 0.3) vs. -0.1 (-0.6 – 0.4) Disability: -1.0 (-2.0 – 0.1) vs. -0.7 (-1.8 – 0.4) Short term: V Pain: - 0.2 (-0.7 – 0.3) vs. 0.0 (-0.5 – 0.4) RMDQ : -0.5 (-1.7 – 0.7) v.s -0.1 (-1.3 – 1.1) Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: global precieved effects: Results: Immediate post tx at 4 wks 0.2 (95% CI: -0.1 – 0.6) vs. 0.0 (-0.3 – 0.3) Short term: 0.3 (-0.1 – 0.6) vs. 0.1 (-0.3 – 0.4) Intermediate: NR Long term: NR Harms: NR
Hurley DA (2004)149 Country: Ireland Quality score: 6/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 8 wks Final assessments: discharge, 6 mos and 12 mos N screened: 569 N randomized: 240 N completed tx: 240 N attended last fu: 158 Inclusion: Pts aged 18-65 yrs with acute LBP (duration: 4-12 wks) with or without pain irradiation to the buttock or legs Exclusion: Previous spinal surgery, motor vehicle accidet, systemic disease, concurrent medical or musculoskeletal conditions, contraindication to manual therapy, psychiatric illness, lack of fluence in English RMDQ < 4 points, pregnancy | Mean age (SD/range): IG = 39.6 (11.6), IG2 = 40.2 (12.1), CG = 40.5 (11.3) yrs % of male: IG = 54%, IG2 = 50%,CG = 52% Racial composition: NR Work status: Employed: IG = 19%, IG2 = 23%, CG = 20% Other socio-demographics: Non-smokers: IG = 49%, IG2 = 42%, CG = 39% Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR | Cause of Pain: Work-related Duration of Pain: Acute, IG = 7.5 (3.1) wks, IG2 = 7.6 (3) wks, CG = 8.3 (2.8) wks Severity of pain (Grading): NR Co-interventions: NR Prior surgery related to current complaint: NR | Groups IG (n = 80)– MT: Mobilization/manipul ation techniques that passively move an intervertebral joint within or beyond its existing ROM described my Maitland; 8 wks Drop outs: D = 26 CG1 (n = 80) – IFT: Omega Inter 4150 portable IFT unit (freq: 3.85 kHz, beat freq: 140 Hz, 130 microsec), spinal nerve root electrode placement method via two Reply 658 carbon silicone self-adhesive electrodes 50 x100 mm; as IG Drop outs: D = 23 CG2 (n = 80) – MT + IFT: Both protocols explained above provided with MT first and then IFT second; as IG Drop outs: D = 27 | Outcomes: Pain: VAS, mean change from baseline Disability: RMDQ-mean chage from baseline Results- Immediate post tx Pain: -19.8 vs. -21.4 vs. -24.7 Disability: -4.5 vs. -3.6 vs. -4.7 Short term: NR Intermediate: Pain: -17.0 vs. -24.6 vs. -20.0 Disability: -4.7 vs. -3.9 vs. -4.6 Long term: Pain: -18.2 vs. -26.5 vs. -25.7 Disabiltiy: -4.7 vs. -4.9 vs. -6.5 | QoL: EQ-5D Weighted Health Index, mean change from baseline Other: short term SF-36 physical functiuoning, mean change from baseline Immediate post tx: EQ-5D: 0.16 vs. 0.16 vs. 0.15 SF-36: 15.2 vs. 10.6 vs. 14.3 Short term: NR Intermediate: EQ-5D: 0.17 vs. 0.16 vs. 0.16 SF-36: 12.6 vs. 10.1 vs. 14.4 Long term: NR EQ-5D: 0.15 vs. 0.20 vs. 0.25 SF-36: 9.4 vs. 11.7 vs. 21.4 Harms: No AEs were reported. One Pts died due to causes unrelated to LBP or PT
Farrell, JP (1982) 150 Country: Australia Quality score: 4/13 Initial of reviewer: ST | Trial Design: RCT Tx duration: 3x/wk for up to 3 weeks. Final assessments: 3 weeks from date of initial treatment N screened: 56 N randomized: 48 N completed tx: 48 N attended last fu: NR Inclusion: Either sex aged 20-65 with pain on lumbar movements or straight leg raising, pain centrally or pravertebrally between T12 and gluteal folds, symptoms of 3 wks durations, experienced a pain-free period of 6 mnths prior. Exclusion: Had other treatment for the current episode of LBP, pregnant, signs of caudaequinal pressure, alterered sensation, reflexes or weakess in lower extremities, previous surgery in the lumbar region, history of fracture in the lower thoracic lumbar region, evidence of systemic disease or carcinoma. | Mean age: IG = 43.4; CG = 41.83 % of male: IG = 67%; CG1 = 58% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: NR Duration of Pain: Acute Severity of pain (Grading): Numerical Rating Scale: (0 – 10) IG = 4.95 (estimated based on graph) CG1 = 5.25 (estimated based on graph) Co-interventions: NR | Groups IG (n = 24)– passive mobilisation and manipulation – techniques descrbeid by Stoddart and Maitland. Drop outs: NR CG (n = 24) – Received 15 minutes of microwave diathermy in a combfortable side-reclining position ; 10 repittioan of isometric abdominal excrcies which the subject also carried out independently another 3-4 times a day; ergonomic instructions which include advice on activities such as lifting, sitting, standoing, carrying objects and rest postures. Drop outs: NR | Outcome instruments: Pain: Mean subjective pain rating (0-10) Disability: NR Results: Baseline: Pain: (estimated based on graph) IG = 4.95 CG = 5.25 Disability: NR Immediate post tx: Pain: (estimated based on graph) IG = 3.80 CG = 4.40 Disability: NR Short term: (estimated based on graph) (after 3rd tx) IG = 2.95 CG = 2.75 (3 wks after initial tx) IG = 0.30 CG = 0.30 Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Results: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR Summary Pts with acute LBP treated by passive mobilisation and manipulation had a shorter mean duration of symptoms compared with those who were treated by microwave diathermy, isometric abdominal exercises and ergonomic instructions.

Table 1.23 Low Back Pain – Manipulation + Mobilization – Chronic-Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Aure (2003)151 Country: Norway Quality score: 8/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 8 wks Fu duration: 6 mos N screened: 60 N randomized: 49 N completed tx: 49 N attended last fu: 49 Inclusion: Men and women age 20-60 yrs sick-listed between 8 wks and 6 mos due to LBP with or without leg pain. Exclusion: Unemployment or early retirement because of LBP; prolapsed with neurologic signs and symptoms requiring surgery; pregnancy; spondylolisthesis; spondylolysis;degenerati ve olisthesis; fractures; suspicion ofmalignancy; osteoporosis; previous back surgery; known rheumatic, neurologic, or mental disease | Mean age (SD/range): IG = 38.9 (12.85) vs. CG = 41.1 (10.76) yrs % of male: IG = 52%, CG = 54% Racial composition: NR Work status: all pts sick-listed for 8 wks-6 mo Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Chronic, IG = 16 (17.23), CG = 10 (10.77) yrs Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 27) – Spinal manipulation, S Mob, and stretching techniques described by Evjenth, Hamberg, and Kaltenborn were allowed; 16 tx, 45 min/ each, 2 tx/wk for 8 wks, max. 6 home EXs during tx period Drop outs: B=2 CG (n = 22) – Exercise therapy: 45 min of training, EX programs designed based on pt examination, group training and massage not allowed; same as IG Drop outs: B=1 | Outcomes: Pain: VAS 100 mm Disability: Oswestry Disability Index (ODI) Results- Immediate post tx: Pain: IG=22 (18.56) CG = 37 (25.12) Disability: IG = 18 (13.26), CG = 30 (10.77) Short term: VAS: IG=22(19.88), CG = 39 (22.53) ODI: IG=18(11.93) CG = 30 (14.36) Intermediate: VAS: IG=21 (14.58) CG = 35 (35.89) ODI: IG = 17 (13.25), CG = 26 (14.36) Long term: NR | Outcome instruments: QoL/ well being: General health (data not shown) Other pts sick listed At entery: 100% on partial or full time sick leave Immediate post tx: 9 (33%) vs. 16 (73%) Short term (4 wks) 8 (30%) vs. 12 (57%) Intermediate (6 mos): 3 (1150 vs. 13 (62%) Long term (12 mos): 5 (19%) vs. 13 (59%) Harms: NR
Ferreira ML (2007)152 Country: Australia Quality score: 7/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 8 wks Final assessments: 6 mos N screened: NR N randomized: 240 N completed tx: 240 N attended last fu: 211 Inclusion: Pts with N-S CLBP (≥ 3 mo) aged 18-80 yrs; pts with OA, disc protrusion, or herniation without neurological compromise were also included Exclusion: Serious low back pathology, contraindications to EX or SM therapy, neurological signs, spinal pathology, or back surgery | Mean age (SD/range): IG1 = 54 (14.4), IG2 = 51.9 (15.3), CG = 54.8 (15.3) yrs % of male: 31% total sample Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: N-S Duration of Pain: Chronic, IG1 = 60 mo, IG2 = 36 mo, CG = 60 mo Severity of pain (Grading): NR Co-interventions: None | Groups IG1 (n = 80) – SM: Joint Mob or manipulation techniques applied to spine or pelvis, doses and techniques prescribed based on pts’ exam results; 12 sessions, 8 wks Drop outs: D = 7 IG2 (n = 80)– MC-EX: improving function of trunk muscles (transversus abdominis, multifidus, the diaphragm, and pelvic floor muscles; cognitive-behavioural therapy encouraging skill acquisition; same as IG1 Drop outs: D = 15 CG (n = 80) – GEN-EX: 'Back to Fitness' program; 12 1 hr sessions, 8 wks Drop outs: D = 7 | Outcomes: Pain: VAS Disability: RMDQ Results- Immediate post tx: Pain: 4.1 (2.6) vs. , 4 (2.5 ) vs. 4.8 (2.4) Disability: 7.9 (6) vs. 7.9 (5.7) vs. 9.7 (6.3) Short term: NR Intermediate: VAS: 4.3 (2.6), vs. 4.3 (2.6) vs. 4.8 (2.6) RMDQ: 7.7 (6.2) vs.8.4 (6.4) vs. 10.1 (7) Long term: VAS: 4.9 (2.7) vs. 4.9 (2.9),vs. 5.2 (2.8) RMDQ: 9.2 (6.6) vs. 8.8 (6.5) vs. 9.6 (6.9) | Outcome instruments: QoL: Global precieved effect Results: Immediate post tx: 2.3 (2.2) vs. 2.8 (1.8) vs. 1.0 (2.8) Short term: NR Intermediate: 1.7 (2.6) vs. 1.9 (2.4) vs. 1.4 (2.4) Long term: 1.2 (2.9) vs. 1.8 (2.5) vs. 1.0 (2.8) Harms: No AEs were reported. Summary: There were no apparent differences between groups in either primary or secondary variables at 6 or 12 mos.

Table 1.24 Low Back Pain – Manipulation + Mobilization – Mixed-Specific Pain-No trials

Table 1.25 Low Back Pain – Manipulation + Mobilization – Mixed-Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Chiradejnant A, (2003)153,154 Country: Australia Quality score: 5/13 Initial of reviewer: FY | Trial Design-RCT Tx duration: 1 session Fu duration (last assessment): immediately post tx N screened: N randomized: 140 N completed tx: 140 N attended last fu: 140 Inclusion: Pts with LBP and resting pain > 2 on a 0-10 scale; candidate for mobilization by PT Exclusion: red flag conditions such as malignancy or inflammatory or infectious diseases affecting the spine | Mean age (SD/range): 47.4 (16.4) vs. 45.4 (16.5) % of male: NR Racial composition: NR Other socio-demographics: work loss (days) 4.7 (8.9) vs. 3.9 (7.7) Co morbidities: NR Prior episode of pain if acute: NA Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: LBP- NS Some with leg numbness (15.7% vs. 22.9%) Duration of Pain, mean Mixed, 184.1 (539.9) vs. 89.3 (279.7) days Severity of pain (Grading): NR Current treatment/ co-intervention common in all groups: NR | Groups IG1 (n = 70) – PT selected correct mobilization technique By qualified PTs Single session Drop outs: 0 IG2 (n = 70) – randomly selected mobilization technique Drop outs: 0 | Outcomes: Pain: VAS Disability: NR Well being: global perceived effect (11 point scale) Results: Immediate post tx: Change from baseline: Pain: Current pain intensity 1.3 (1.4) vs. 1.2 (1.7) On most painful movement 1.7 (1.7) vs. 1.4 (1.50 % reduction of pain intensity 29.7 (32.7) vs. 23.9 (37.9) Global perceived effect: 1.4 (1.8) vs. 1.2 (1.9) | Outcomes: Range of movements (ROM) Change from baseline: Finger to floor (cm): 2.0 (2.6) vs. 0.5 (5.6) Flexion: -3.5 (3.8) vs. -1.9 (6.5) Extension (degrees) -2.2 (2.9) vs. -2.6 (2.8) Right lateral flexion: -2.0 (2.5) vs. -1.9 (2.7) On most painful movement: -3.2 (3.2) vs. -2.1 (6.3) Harms: NR
Goodsell, M (2003)155 Country: Australia Quality score: 3/13 Initial of reviewer: FY | Trial Design-RCT-cross over Tx duration: 1 session Fu duration (last assessment): immediately post tx N screened: NR N randomized: 26 N completed tx: 26 N attended last fu: 26 Inclusion: Pts with LBP in last 48 hours, back pain elicited or increased by active lumbar flexion or extension movements, pain elicited on application of force to the spinous process of 1 or more lumbar vertebrae Exclusion: known contraindication to manual therapy such as malignancy, inflammatory or infectious disease affecting the spine, or pregnancy | Mean age (SD/range): NR % of male: 58 vs. 36% Racial composition: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NA Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: LBP-NS Some with leg numbness (15.7% vs. 22.9%) Duration of Pain, mean Mixed, 184.1 (539.9) vs. 89.3 (279.7) days Severity of pain (Grading): NR Current treatment/ co-intervention common in all groups: NR | Groups IG (n = 12) – Lumbar postero-anterior mobilization applied to the most symptomatic spinal level 3 x 1 minute reps-magnitude adjusted at PTs discretion Drop outs: 0 CG (n = 14) – Control prone lying for 3 minutes Drop outs: 0 | Outcomes: Pain: VAS Results: Immediate post tx: Change from baseline: Pain: In flexion -6.1 vs. -2.0 In extension (mm) -7.4 vs. -3.0 Worse pain (mm) -13.4 vs. -3.5 Overall (%) -24.5 vs. -11.1 | Outcomes: Range of movements (ROM) Change from baseline: Finger to floor (cm): 1.9 vs. 1.8 Flexion (degrees) 0.9 vs. 1.4 Extension 0.9 vs. 1.4 Harms: NR
Himmilä, HM (2002)156 Country: UK Quality score: /13 Initial of reviewer: FY | Trial Design-RCT Tx duration: 1 session Fu duration (last assessment): same day-immediately post tx N screened: NR N randomized: 26 N completed tx: 26 N attended last fu: 26 Inclusion: ambulatory pts with back pain longer than 7 weeks Exclusion: Patients with back pain less than 7 weeks- | Mean age (SD/range): all pts: 38.3 (11.7) range 18-61 % of male: 58% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | LBP-NS. Duration of Pain, mean (SD/range): All pts 26.8 (47.9) range 0.1 – 240 months Severity of pain (Grading): NR Current treatment/ co-intervention common in all groups: no therapies were allowed for 1 month prior to the study | IG (n = NR )– spinal mobilization applied centrally or unilaterally; between 1 and 3 levels, using 2-3 set of 4-6 reps. (MWM technique) By senior PTs with mean 9 years post graduate experience and accredited MVM course-one session only Drop outs: 0 CG1 (n = NR)– Placebo mobilization with only postural placement of subjects similar to the intervention group (instruction was to relax) One session only Drop outs: 0 | Outcomes (describe instrument used): Pain by VAS Disability by RMDQ Results: Baseline: VAS at worst 7.0 (2.0) ; During flexion 5.2 (1.9) Disability: 11.4 (4.7) Immediate post tx: Pain: post placebo: 4.3 (2.2) Post MWM 4.2 (2.5) | Outcomes (describe instrument used): Spinal ROM Immediate post tx: post placebo total flexion: 69.7 (21.5); total extension 21.2 (11.1) Post MWM total flexion 76.7 (22.4); total extension 24 (11.0) Short term: NA Intermediate: NA Long term: NA Harms: NR
Hurwitz EL (2006)157 Country: US Quality score: 6/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 6 wks Fu duration: 18 monhts N screened: 2355 N randomized: 681 N completed tx: 681 N attended last fu: 610 Inclusion: age 18 or older Health maintenance organization membership, sought care in one of the study sites between 1995-1998 with LBP, had no Tx received for the past mo, Exclusion: Pain due to fracture, tumor, infection, spondyloarthropathy, or other non-mechanical cause, blood disorder or received anticoagulants or corticosteroids, no ability to speak English | Mean age range: 49 – 53 yrs % of male: 48.1 (avg for all grps) Racial composition: majority (> 60%) White Work status: NR Other socio-demographics: Married: majority with high school or college education & married; > 50% employed - < 2% on leave Co morbidities: NR | Cause of Pain: Traumatic back injury-avg 27.1 Radiating pain: leg pain below knee-avg 34.2 Duration of Pain: Acute, 26.1 Sub-acute, 15.7 Chronic, 11.6 Severity of pain (Grading): NR Co-interventions: NR | Groups IG1 (n = 169)– SM or Mob + advise & EX Drop outs: 12 monhts = 16 IG2 (n = 172) – SM or Mob + PM (heat/cold, ultrasound, EMS) Drop outs: 12 monhts = 16 CG1 (n = 170) – medical care: advise + analgesics, muscle relaxants, anti-inflammatory Drop outs: 12 monhts = 17 CG2 (n = 170) – medical care + PM Drop outs: 12 monhts = 22 | Outcome instruments: Pain: VAS Disability: RMDQ Results- Immediate post tx: Most severe pain: IG1 = 1.83, IG2 = 1.95 Average pain: IG1 = 1.04, IG2 = 1.35 Disability-mean: IG1 = 3.18, IG2 = 3.16 Short term: NR Intermediate: NR Long term: Pain-mean: IG1 = 2.51, IG2 = 2.51; IG1 = 1.73, IG2 = 1.82 Disability-mean: IG1 = 4.41, IG2 = 3.68 | Outcome instruments: QoL/ well being: NR Results: Immediate post tx: Short term: NR Intermediate: NR Long term: NA Harms: NR Summary: mean changes in pain intensity and disability IG 1&2 were similar at each fu (adjustedmean differences at 6 mos for most severe pain, 0.27, 95% CI: -0.32– 0.86; average pain, 0.22, -0.25– 0.69; and disability, 0.75, -0.29 –1.79). PT yielded somewhat better 6-mo disability outcomes than did medical care alone (1.26, 0.20– 2.32).
Koes, B (1992)158 Country: Netherlands Quality score: 5/13 Initial of reviewer: SG | Trial Design- RCT Tx duration: 6 and 12 wks Final assessments: 12 wks N screened: NR N randomized: 136 N completed tx: NR N attended last fu: NR Inclusion: pain or self-reported limited ROM in the back or neck for at least 6 wks Exclusion: suspicion of underlying pathology (e.g., malignity, osteoporosis, herniated disc), tx with PT or manual therapy for back or neck complaints during past 2 yrs, pregnancy, language problem or inability to reproduce complaints by active or passive movements during physical examination. | Mean age (SD/range): 42.75 yrs total % of male: IG1 = 46% IG2 = 52%, CG1 = 62%, CG2 = 48% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Sub-acute, Chronic; 26-92 wks Severity of pain (Grading): NR Co-interventions: NR | IG1 (n = 36)– SM + Mob of the spine according to Dutch Society for manual therapy ; max. 3 mo Drop outs: B = 3,D = 10 IG2 (n = 31)– Physiotherapy: EX, massage, heat, electrotherapy, ultrasound, short-wave diathermy Drop outs: B = 5,D = 17 CG1 (n = 39)– General practitioner: continued tx with GP, prescription, advice on posture, EX, sports and bed rest; as IG1 Drop outs: B = 7 CG2 (n = 30) – Placebo: physical exam detuned diathermy (10 min) and ultrasound (10 min); 2 tx/wk for 6 wks; Drop outs: B = 8 | Outcome instruments: Pain: NR Disability: NR Results: Immediate post tx: Pain: Disability: ---- Short term: Intermediate: Long term: | Outcome instruments: QoL/ well being: NR Other: Immediate post tx at 3 mos: Improvement in physical functioning: 4.0 (2.3) vs. 3.2 (2.0) vs. 3.4 (2.3) vs. 3.4 (2.2) Spinal flx at T1 (degrees)- change in ROM: -2.0 (15) vs. 6 (13) vs. 0 (10) vs. 0 (18) Short term: NR Intermediate: NR Long term: NR Harms: NR
Macdonald, R (1989)159 Country: London Quality score: 5/13 Initial of reviewer: SG | Trial Design- RCT Tx duration: until cured Final assessments: immediately post tx N screened: 100 N randomized: 95 N completed tx: 90 N attended last fu: NR Inclusion: Pts 16-70 yrs with pain partly or wholly; the inferior angles of the scapulas to the buttock folds Exclusion: inflammatory joint disease, skeletal metastases or infection, spondylolisthesis, neurologic deficit in structures innervated by lumbar or sacral roots that could not be ascribed to a previous resolved episode or other pathology, osteomalacia/ osteoporosis, visceral pathology that could refer LBP, pregnancy, sought physical tx outside the practice for their present episode, transient pts | Mean age (SD/range): NR % of male: IG = 43%, CG = 39% Racial composition: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: 1-12 mos prior IG - (26), CG – (21); 1-6 yrs prior IG - (28), CG – (23) Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Acute Severity of pain (Grading): Pain Analog (0-75)(A) Co-interventions: NR Work status: Men having physically active work (36%) Women having physically active work (16%) | Groups IG (n = 49) – Osteopathic manipulation therapy (OMT): advice on posture, EX,. Osteopathic tx given: direct pressure and stretching to involved musculature, LVHA oscillatory movements to hypomobile joints, HVT to hypomobile vertebral motion segments; 2 tx/wk until pts deemed themselves recovered or further tx believed unlikely to produce benefit Drop outs: B = 5 CG (n = 46) – Control: Advice on posture, EX, pts seen in clinic as necessary Drop outs: NR | Outcomes: Pain: PDI (0-10);Pain analog (PA) (0-75) Disability: Activity Loss (ALA) Results: Baseline: Pain: PDI: IG = 6.4 (3), CG = 6.1 (2.5) PA: IG = 18.9 (10), CG = 20.3 (9.2) Disability: IG = 34.9 (23.1), CG = 22.8 (14.9) Immediate post tx: Pain: NR Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Results: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: n = 20, Excess Lumbar Lordosis; n = 21, Pins and needles
Powers, C (2008)160 Country: US Quality score: 3/13 Initial of reviewer: FY | Trial Design- RCT Tx duration: 1 session Fu duration (last assessment): same day-immediately post tx N screened: NR N randomized: 30 N completed tx: 30 N attended last fu: 30 Inclusion: adults 18 to 45 years of age with diagnosis of nonspecific LBP < 3 months with localized LBP at or above the waist level, decreased lumbar extension assessed by qualitatively while standing Exclusion: Patients older than 45 years to control for confounding of osteoarthritis; spinal malignancy, cardiovascular disease, evidence of cord compression, aortic aneurysm, hiatal hernia, uncontrolled hypertension, abdominal hernia, prior LBP surgery | Mean age (SD/range): 30.2 (7.9) vs. 32.3 (9.6) % of male: 35% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: pts with prior surgery were excluded | LBP-NS. Duration of Pain, mean (SD/range): Severity of pain (Grading): NR Current treatment/ co-intervention common in all groups: NR | IG (n = 15 )– spinal mobilization (Maitland method) one session only Drop outs: 0 CG1 (n = 15)– press up exercise as far as possible without reproducing lumbar pain with standing extension (according to the McKenzie and May technique) One session only Drop outs: 0 | Outcomes (describe instrument used): Pain by VAS Disability: NR Results: Baseline: 4.1 (1.7) vs. 4.0 (2.1) Immediate post tx: 2.4 (1.8) vs. 2.8(1.5) Average change from baseline 1.7 (2.1) vs. 1.2 (1.4) | Outcomes (describe instrument used): Lumbar extension (degrees): Baseline: 20.2 (5.2) vs. 22.2 (3.9) Immediately post-tx: 23.8 (6.5) v.s 24.9 (6.0) Average change form baseline: 3.6 (5.0) vs. 2.7 (5.1) Short term: NA Intermediate: NA Long term: NA Harms: NR

Table 1.26 Low Back Pain – Manipulation + Mobilization – Unknown -Specific Pain -No trials

Table 1.27 Low Back Pain – Manipulation + Mobilization – Unknown -Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Meade TW (1991)161 Country: UK Quality score: 5/13 Initial of reviewer: SG | Trial Design- RCT Tx duration: 3-12 mo Final assessments: 1 yr N screened: 781 N randomized: 741 N completed tx: 741 N attended last fu: 541 Inclusion: LBP mechanical origin, no contraindication to SM, no Tx within the past mo Exclusion: Nerve root damage, major structural abnormalities visible on radiography, osteopenia, or infection | Mean age (SD/range): IG = 38.9 (11.2) vs. CG = 38.3 (10.8) yrs % of male: IG = 49%, CG = 53% Racial composition: Work status: Self-employed: IG = 11%, CG = 13% Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Mechanical Duration of Pain: NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG1 (n = 384)– Chiro: Tx at the discretion of chiropractors who used chiro manipulation on most pts; max. 10 sessions for 3-12 mo, tx completed in 30 wks Drop outs: E = 137 IG2 (n = 357) – HM: Maitland Mob/manipulation; tx completed in 12 wks Drop outs: E = 150 | Outcome instruments: Pain: Oswestry Disability Questionnaire; ODQ(pain intensity) Results: Immediate post tx: NR Short term: Disability-mean change: IG1 = 1.03, IG2 = 0.67 Intermediate: Disability-mean change: NR; IG1 = 0.94, IG2 = 0.73 Long term (1 yr) Pts with no pain: 59% vs. 64% Disability-mean change: NR; IG1 = 0.98, IG2 = 0.63 | Outcomes: QoL/ well being: NR Mean changes in SLR (degrees) in 6 wks:Right leg: 5.0 vs. 7.1 Left leg: 0.62 vs. 0.85 Using drugs, %: 35% vs. 33% Harms: NR (pts with further requally severe pain at 1 yr: 25% vs. 24%) Summary: at 2 yrs post-R, for those with ODQ > 40%, > improvement in ODQ scores between IG1 vs. IG2 (between-group difference: 13.3, 95% CI: 0.24, 26.01) compared to those with ODQ ≤ 40% at baseline (between-group difference: 3.19, 95% CI: -1.52, 7.90)
Sims-Williams H (1979)162 Country: UK Quality score: 4/13 Initial of reviewer: SG | Trial Design- RCT Tx duration: 4 wks Final assessments: 3 mos & 1 yr (postal questionnaire) N screened: NR N randomized: 94 N completed tx: 94 N attended last fu: 80 Inclusion: pts with N-S LBP Exclusion: contraindications to tx | Mean age (SD/range): IG = 43 (11.8) vs. CG = 42.3 (12.7) yrs % of male: IG = 64.5%, CG = 52.1% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S, n (%) radiating pain: IG = 15 (31.2%), CG = 4 (8.7%) Duration of Pain: NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 48) – SMM: based on a method described by Maitland; daily for 1^st^ wk, then 3 times/wk for 3 wks, 4 wks total Drop outs: D = 14 (both arms) CG (n = 46) – Placebo: microwave at the lowest setting directed to the lumbar spine for 15 min with the pt prone; same as IG Drop outs: see above | Outcome instruments: Pts with no pain (completely better) Disability: subjective assessment of physical activity Results- Immediate: Pts with no pain: 4/48 vs. 1/48 Much better in pain: 13 vs. 14 Combined 17 vs. 15 Back to normal activity (no. of pts): 19 vs. 20 Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Flexion; Extension Immediate post tx: Disability: IG = 24 (10.3), CG = 22.75 (9.62); IG = 42.96 (9.09); CG = 44.43 (11.38) Short term: IG = 26.83 (9.41), CG = 22.46 (9.43); IG = 43.13 (9.93), CG = 44 (11.85) Intermediate: NR Long term: NR Harms: NR

Table 1.28 Low Back Pain – Flexion Distraction Technique – Acute/Subacute- No studies

Table 1.29 Low Back Pain – Flexion Distraction Technique – Chronic- Specific- No studies

Table 1.30 Low Back Pain – Flexion Distraction Technique – Chronic -Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Cambron JA (2006)163 Country: US Quality score: 3/13 Initial of reviewer: SG | Trial Design- RCT Tx duration: 4 wks Fu duration:1 yr N screened: 2176 N randomized: 235 N completed tx: 235 N attended last fu: 174 Inclusion: aged > 18 yrs with CLBP > 3 mo from L1 to S1 joint inclusive, willing to undergo narcotic/NSAIDs muscle relaxant's use Exclusion: CNS disease, contraindication to MT, severe osteoporosis, lumbar fracture, systemic disease affecting muscoskeletal system, psychiatric disease, alcohol/drug abuse, morbidly obese, pregnant, currently receiving Tx for LBP | Mean age : 42 yrs % of male: IG = 66%; CG = 59% Racial composition: Majority White (82%) Work status: NR Other socio-demographics: Married:59.5% Co morbidities: Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Chronic, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 123) – Chiro (flx + distraction): (FD) was done on a table with a pt lying in prone position the clinician placed one hand over the lumbar region at the spinal level of interest and used the other hand to flex or rotate the lower extremity section of the table; 2-4 times/wk, 4 wks Drop outs: E = 27 CG (n = 112) – Exercise: Strength, flexibility, and CV EXs; same as IG Drop outs: E = 34 | Outcome instruments: Pain: VAS Disability: RMDQ Results- Immediate post tx: Pain: 14.6 (1.7) vs. 19.7 (2) Disability: 3.6 (0.4) vs. 3.8 (0.4) Short term: Pain: 19.3 (2.1), vs. 22.1 (2.2) RMDQ: 2.7 (0.4) vs. 2.9 (0.4) Intermediate: Pain: 19.2 (2) vs.3.8 (2.4); RMDQ: 2.6 (0.4) vs. 3.4 (0.5) Long term: Pain: 20.6 (1.9) vs. 21.6 (2) RMDQ: 2.9 (0.4) vs. 3.2 (0.4) | Outcomes: QoL/ well being: NR Other: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NA Harms: No AE occoured within either tx grps Summary: Pts in IG experienced greater improvements in pain compared to CG; no differences were seen in disability between the two groups

Table 1.31 Low Back Pain – Flexion Distraction Technique – Mixed - Specific- No studies

Table 1.32 Low Back Pain – Flexion Distraction Technique – Mixed -Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Hawk, C (2005)164 Country: Midwestern US Quality score: 8/13 Initial of reviewer: SG | Trial Design- RCT Tx duration: 3 wks Fu duration: imm.post-tx N screened: 230 N randomized: 111 N completed tx: 106 N attended last fu: 106 Inclusion: 18 yrs and over, with sub-acute (onset 4-12 wks prior to contact) or CLBP (onset more than 12 wks prior) Exclusion: Pregnancy, radiation of pain distal to the knee with evidence of neurologic involvement, contraindications to manipulation, no indications of musculoskeletal dysfunction, litigation for a health-related claim, chiropractic care within the last mo, or unwillingness to postpone other types of manual therapy during the study | Mean age: 52 yrs % of male: IG = 50%; CG = 44% Racial composition: 52% White Work status: ds of missed work in past mo: 0 Other socio-demographics: 13% Smokers Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: sub-acute or chronic, (median) IG = 4 yrs, CG = 7 yrs Severity of pain (Grading): NR Co-interventions:NR | Groups IG (n = 54) – Manipulation: pressure applied to lumbar/lumbosacral region with PA force of 80-160 N, Trigger point therapy: 40-75 N for 4-7 sec, releasing for 3-5 sec with a max. of 3 reps; 8 tx over 3 wks Total Drop outs: A = 119, B = 15 CG (n = 57) – Control tx: Instrument set to its “zero point” delivering weight of instrument, applied 2 inches lateral to spine and not more than 12 N, effleurage applied to pt’s low to middle back for 5-10 sec at 10-20 N; same as IG | Outcomes: Pain: PDI; RMDQ Results: Baseline: Pain: IG = 26.8 (12. 1), CG = 26.1 (12) RMDQ: IG = 7.4 (3.9), CG = 7.8 (4.6) Immediate post tx: Pain-mean change: IG = 9.1, CG = 7.9 RMDQ: IG = 2.2, CG = 1.5 Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Number of pts with overall complete improvedment: Results: Immediate post tx: 0 vs. 1 Short term: NR Intermediate: NR Long term: NR Harms: N = 1 in IG, BP became worse during visit ; n=1 WDAE in IG vs. 0 in CG
Hawk, C (1999)165 Country: US Quality score: /13 Initial of reviewer: SG | Trial Design-RCT Crossover Design Tx duration: 2 wks Final assessments: 2 wks N screened: 18 N randomized: 13 N completed tx: 13 N attended last fu: 13 Inclusion: 18 yrs of age or older; self-report of LBP within the last 6 mo Exclusion: Unsuited to chiropractic tx: the clinician took a case history on all pts and completed a screening orthopedic and neurological examination to rule out contraindications to chiropractic tx; litigation; pregnancy | Mean age (SD/range): 33.5 yrs (all grps) % of male: 66.6% all grps Racial composition: NR Work status: chiropractic college students or faculty or staff members. Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Unknown Severity of pain (Grading): NR Co-interventions:NR | Groups IG (n = 8) – Active tx first, symptomatic pts: Chiropractic Adjustment (active) - Flexion-distraction technique.; 4 visits, 2 wks Drop outs: 0 CG (n = 5) – Placebo tx first, symptomatic pts: Sham adjustments were performed with a hand-held instrument used in certain chiropractic techniques; as IG Drop outs: 0 | Outcome instruments: Pain: VAS (10 cm) Results: Immediate post tx: Pain-mean change: decrease in pain in IG vs. increase in CG: -0.7 vs. +0.5 Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Global well being: results reported for individual pts- not shown Short term: NR Intermediate: NR Long term: NR Harms: one pts showed a negative response to both tx with decrease in the GWBS of 1.10 cm for the active tx and 0.20 cm for the placebo; another Summary: improvements were greater after IG than CG

Table 1.33 Low Back Pain – Flexion Distraction Technique – Unknown - Specific- No studies

Table 1.34 Low Back Pain – Flexion Distraction Technique – Unknown -Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Beyerman KL (2006)166 Country: US Quality score: 4/13 Initial of reviewer: SG | Trial Design- RCT Tx duration: 5 wks Final assessments: 5 wks N screened: NR N randomized: 217 N completed tx: 217 N attended last fu: 217 Inclusion: English speaking pts with arthritis, OA, degenerative joint/disc disease, facet arthropathy, capable of traveling to the appointments Exclusion: Present use of chiro therapy, PT, or anti-inflammatory Meds | Mean age (SD/range): NR % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: osteoarthritis Duration of Pain: NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 124) – FD + moist hot pack: impulsion, FD in prone position secured to table with strap around ankles; traction in lumbar spine; flx added by using distractive repetitions of the table manually controlled; hot packs applied for 15 min, 2-3 visits/wk, 5 wks Drop outs: n = 35 (total sample) CG (n = 93) – Moist heat: hydro collator pack stored at 150-170 degrees; using 6 layers of towel covering, 3 between the skin and hot pack and 3 on the transverse oscillatory rot of the hot pack; as IG | Outcome instruments: Disability: ODQ (pain intensity); ODQ (ADL) Results: Immediate post tx: Disability: IG = 0.69 (1.15), CG = 1.31 (1.45); ODQ: IG = 8.56 (7.1), CG = 12.82 (7.66) Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Other: NA Results: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: no AEs was repoted by pts

Table 1.35 Low Back Pain - Massage — Acute/Sub-acute - Specific Pain — No studies

Table 1.36 Low Back Pain - Massage — Acute/Sub-acute - Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Farasyn A (2006)167 Country: Belgium Quality score: 7/13 Initial Of reviewer: SG | Trial Design-RCT Tx duration: One session Final assessments: Post-tx N screened: 170 N randomized: 60 N completed tx: 60 N attended last fu: 60 Inclusion: 21-75 yrs; N-S subacute LBP with or without referred pain to the leg Exclusion: Acute (3 wks) and chronic (> 12 wks) LBP and/or neuropathy (sciatica or severe root compression); Fibromyalgia; use of any Med, and/or psychological tx; pregnancy and the existence of any significant pathology (no reported abnormal spinal x-ray findings e.g. spinal fracture, tumor, infection, structural deformity, inflammatory disorders) | Mean age (SD/range): IG = 41 (11), CG1 = 43 (12), CG2 = 40 (12) yrs % of male: IG = 35, CG1 = 45, CG2 = 44 Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: N-S Duration of Pain: Sub-acute, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 20)– Roptrotherapy: deep cross-friction massage with the aid of a myofascial T-bar made of bronze, applied within the tolerable threshold of one 30 min session Drop outs: 0 CG1 (n = 20) – Endermology - a LPG device was adjusted to a minimal but continuous suction power s; same as IG Drop outs: 0 CG2 (n = 20) – no as IG ayed tx); same as G Drop outs: 0 | Outcome instruments: Pain: VAS (100 mm) Disability: ODI – Dutch language version Results: Baseline: Pain: IG = 56 (26), CG1 = 57 (20), CG2 = 49 (22) Disability: IG = 34 (11), CG1 = 36 (11), CG2 = 29 (11) Immediate post tx: Pain: IG = 37 (19), CG1 = 59 (21), CG2 = 52 (21) Disability: IG = 16 (5), CG1 = 38 (11), CG2 = 31 (12) Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR
Aleksiev (1995)168 Country: Bulgaria Quality score: 2/13 Initial of reviewer: FY | Trial Design- RCT-cross over Tx duration: 12 sessions in 20 days Fu duration (last assessment): 1 year N screened: NR N randomized: 26 N completed tx: 26 N attended last fu: 26 Inclusion: Pts with LBP > 1 month more lumbar vertebrae Exclusion: compressive neuropathy, traumatic fractures, spondylolisthesis, osteoporosis, inflammation, or tumors | Mean age (SD/range): NR % of male: Racial composition: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NA Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: LBP-NS Duration of Pain, mean Mixed, mean range 16.7 to 18.1 days Severity of pain (Grading): NR Current treatment/ co-intervention common in all groups: NR | Groups IG1 (n = 29) – post isometric relaxation of the LBP muscles and illiopsoas 12 sessions in 20 days Drop outs: NR IG2 (n = 21) – Average frequency sinuous modulated current tx + sham mobilization 12 sessions in 20 days Drop outs: NR IG3 (n=26): Perl’s traction therapy + sham mobilization 12 sessions in 20 days Drop outs: NR CG (n=19) sham mobilization + NSAIDs 12 sessions in 20 days Drop outs: NR | Outcomes: Pain: VAS Results: Pain: Data presented in graph—not used Summary of findings: statistically significant improvement of pain in mobilization group only immediately post tx All other tx and follow up outcomes were non-significant compare to baseline. Improvements better in IGs vs. CG (p< 0.05) at short term fu All pts were pain free at 1 year fu | Outcomes: Range of movements (ROM) No numerical values reported Harms: NR
Konrad K (1992)169 Country: Hungary Quality score: 6/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 4 wks Final assessments: 6 mos N screened: NR N randomized: 158 N completed tx: 158 N attended last fu: 158 Inclusion: NS LBP with or without radiation to the thigh, 1 mo ≤ duration ≤ 3 mo, a pain free yr before the present episode Exclusion: pregnancy, back surgery, spondylolisthesis, infections, tumors, fractions, ankylosing spondylitis, senile osteoporosis, scoliosis | Mean age (SD/range): IG1 = 42 (8.8), IG2 = 39 (9.1), IG3 = 44 (7.6), CG = 41 (8.6) yrs % of male: 44.7 Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Sub-acute, IG1 = 2.5 (1.1), IG2 = 2.7 (1.4), IG3 = 2.7 (1.8); CG = 2.4 (1.7) mo Severity of pain (Grading): NR Co-interventions: NR | Groups IG1 (n = 35)– Balneotherapy: pts immersed in heated water with minerals; 4 wks Drop outs: 3 IG2 (n = 44)– Underwater traction bath traction was applied; traction belt was applied to the pelvis with 3 kg weight on both sides; As IG1 Drop outs: 0 IG3 (n = 26)– Underwater massage: movement while a stream of hot water played on the affected part; As IG1 Drop outs: 9 CG (n = 53) – No tx Drop outs: NR | Outcomes: Pain: VAS Disability: NR Results: Baseline: Pain: IG1 = 63.4 (24.1), IG2 = 56.7 (28.2), IG3 = 68.4 (31.9), CG = 61.5 (32.8) Disability: ---- Immediate post tx: Pain: IG1 = 31.7 (16.2), IG2 = 24.6 (11.9), IG3 = 33.5 (19. 1), CG = 53.7 (23.8) Disability: ---- Short term: NR Intermediate: VAS: IG1 = 49.5 (25.7), IG2 = 45.8 (26.2), IG3 = 54.7 (33.7), CG = 54.9 (24.8) Long term: NR | Outcome instruments: QoL/ well being: NR Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR
Pope, M (1994)113 Country: California, US Quality score: 5/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 3 wks Final assessments: 3 wks N screened: NR N randomized: 150 N completed tx: 148 N attended last fu: 148 Inclusion: ages 18-55 yrs; general good health; LBP between 3 wks-6 mo; free from LBP for minimum 3 wks Exclusion: pregnancy; sciatica; neurologic deficits, loss of sensation, strength and reflex; no prior vertebral fracture, tumor, infection or spondyloarthropathy; no prior back surgery; Davenport weight index > 33 | Mean age (SD/range): 32 yrs % of male: 62% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: NR Duration of Pain: Mix Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 60)– SM through ROM, end a dynamic short level, HVLA thrust on the lumbar spine and/or sacroiliac joint; 3 x/wk for 3 wks Drop outs: B = 17 CG (n = 30) – Soft-tissue massage: Effleurage in prone - on-rhythmic motion,; 15 min/tx, 3 x/wk for 3 wks Drop outs: B = 10 IG2 (n = 30) – TENS:, max 91 mA, ; 8 hrs/d, on for min. 1 hr at a time; 1x/wk for 3 wks Drop outs: B = 10 IG3 (n = 30) – Lumbo sacral corset during waking hrs except while bathing; 3 x/d; 1x/wk for 3 wks Drop outs: B = 6 | Outcomes: Pain: 10 cm VAS ROM-modified Schober’s test: Flexion; Extension Results- Baseline: Pain: NR Disability: NR Immediate post tx: Pain: IG = -24.1 (27), CG = -17.2 (25.1), IG2 = -9.6 (30), IG3 = -15.9 (27) Disability-mean change: IG = 0.38 (1.25), CG = -0.08 (1.2), IG2 = -0.02 (0.82), IG3 = 0.33 (0.93); IG = -0.29 (0.59), CG = -0.32 (0.63), IG2 = 0.63 (0.89), IG3 = -0.27 (0.72) Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Results: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR Summary of results (if provided): No significant differences were observed for any of the outcomes between txs.
Preyde M6 (2000)170 Country: Guelph, ON Quality score: /13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 1 mo Final assessments: 3 mos N screened: 165 N randomized: 98 N completed tx: 98 N attended last fu: 91 Inclusion: 18-81 yrs; existence of subacute (between 1 wk and 8 mo LBP; stable health Exclusion: Significant pathology, such as bone fracture, nerve damage, or severe psychiatric condition including clinical depression as determined by a physician; pregrnancy. LBP > 8 mo subacute cut-off (15 pts), they were not currently experiencing LBP (13 pts), or a diagnosis of complex health problems such as multiple sclerosis (9 pts) | Mean age (range):42 – 48 yrs % of male: 48.25 Race: NR Work status: 25.5% Unemployed/retired Other socio-demographics: 68.5% Partnered/married Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: Mild strain: 24.2%; Sports injury: 14.5%; Bending/lifting injury: 34%; Fall/accident: 7.25%; Stress related: 6.2% % NS: 14% Duration of Pain: Sub-acute, IG1 = 12 (9.1); IG2 = 14.8 (8.2); CG1 = 13.2 (11.1); CG2 = 13.3 (8.8) Severity of pain (Grading): NR Co-interventions: NR | Groups IG1 (n = 25)– Comprehensive massage+ general strengthening or mobility EXs; 30-35 min/ tx, 6 tx over 1 mo Drop outs: A = 1, B = 0, C = 1 IG2 (n = 25) – Soft-tissue manipulation: same as IG1; 6 tx over 1 mo Drop outs: A = 0, B = 2, C = 3 CG1 (n = 22) – Remedial EXs: as IG1; as IG2 Drop outs: A = 1, B = 1, C = 1 CG2 (n = 26) – Sham laser tx (low level); 20 min/ tx, 6 tx over 1 mo Drop outs: A = 0, B = 1, C = 2 | Outcomes: Pain: McGill: PPI; PRI scores Disability: RDQ (0-24) Results: Immediate post tx: Pain: IG1 = 0.44 (0.6), IG2 = 1.04 (0.7), CG1 = 1.64 (0.8), CG2 = 1.65 (0.8) Disability: IG1 = 2.36 (2.8), IG2 = 3.44 (2.8), CG1 = 6.82 (5.6), CG2 = 6.85 (3.5); Short term: Pain: IG1 = 0.42 (0.6), IG2 = 1.18 (1.5), CG1 = 1.33 (0.8), CG2 = 1.75 (0.6) Disability: IG1 = 1.54 (2), IG2 = 2.86 (3.1), CG1 = 5.71 (4.8), CG2 = 6.5 (4.2) Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Modified schober test (cm) Immediate post tx: IG1 = 6.36 (1.2), IG2 = 5.87 (1.5), CG1 = 5.86 (1.3), CG2 = 5.98 (1.2) Short term: NR IG1 = 6.47 (1.2), IG2 = 5.93 (1.4), CG1 = 5.39 (1.4), CG2 = 5.5 (1.5) Intermediate: NR Long term: NR Harms: NR
Yip, YB (2004)171 Country: China Quality score: 5/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: NR Final assessments: 3 wks N screened: NR N randomized: 61 N completed tx: 51 N attended last fu: 51 Inclusion: pts aged 18 or older with N-S subacute LBP for most ds in past 4 wks; no acu, PT or SM in past wk Exclusion: S cause of LBP; systemic disease, contraindication to massage, pregnant, allergic to natural lavender oil, wound at any of the acupoint of the back or lower limb | Mean age (SD/range): 43.8 (3.0) vs. 48.1 (4.0) yrs % of male: 15% Racial composition: NR Work status: occuPts reported Other socio-demographics: Education levels reported Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: N-S Duration of Pain: Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 32)– Massage: acupoint relaxation flollowod by acupuressure with lavender oil 8 sessions/ 3 wks Drop outs: NR CG (n = 29) – usual care only; as IG Drop outs: NR | Outcome instruments: Pain: VAS Disability: NR Results: Immediate post tx: Pain: ---- Disability: ---- Short term- 4 wks: Pain: 0.61 (0.06) vs. 0.99 (0.06) reduction in pain (VAS) one wk post tx: IG 39% more reduction thant CG Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Other: lateral fingertip to ground (cm) Immediate post tx: NR Short term- 1 wk post tx: 0.96 (0.01) vs. 1.01 (0.01) cm Intermediate: NR Long term: NR Harms: no AEs were reported. Summary:

Table 1.37 Low Back Pain - Massage - Chronic- Specific Pain – No Studies

Table 1.38 Low Back Pain - Massage - Chronic - Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Cherkin, DC (2001)20 Country: U.S Quality score: 6/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 10 wks Final assessments: immediately post tx N screened: 693 N randomized: 262 N completed tx: 249 N attended last fu: NR Inclusion: Ages 20-70 yrs who visited a primary care physician for LBP who had persistent LBP for 6 wks. Exclusion: Sciatica; acu or massage for BP within past yr, back care from a specialist /CAM provider, severe clotting disorders or anticoagulant therapy, cardiac pacemakers, underlying systemic or visceral disease, pregnancy | Mean age (range): 44 – 45 yrs % of male (range): 31 – 48% Racial composition: White: 82 – 89% Work status: employed or self-employed: IG1 and CG = 82%, IG2 = 90% Other socio-demographics: family income > 35K/y: IG1 = 55%, IG2 = 59%, CG = 71% Co morbidities: NR Prior surgery related to current complaint: IG1 = 5%, IG2 = 5%, CG = 8% | Cause of Pain: N-S, Radiation below knee: IG1 = 24%, IG2 = 30%, CG = 31% Duration of Pain: Chronic, % with pain > 1 yr: IG1 = 57%, IG2 = 64%, CG = 62% Severity of pain (Grading): NR Co-interventions: narcotic analgesics: IG1 and CG = 9%, IG2 = 12% | Groups IG1 (n = 94)– Acu: chinese medical acu-, e-stimulation + manual manipulation of the needles, indirect moxibustion, IR heat, cupping,+ EX; up to 10 visits over 10 wks Drop outs: B = 5, E= 2 IG2 (n = 78) Soft tissue manipulation - Swedish massage, movement reeducation, deep-tissue, neuromuscular , and trigger and pressure point;; same as IG1 Drop outs: B = 1, E= 2 CG (n = 90) – Self care: high-quality educational material (book + video tapes); NA Drop outs: B = 7, E= 7 | Outcome instruments: Pain: Symptom bothersomeness during past wk (0-10 scale) Disability: Roland Disability(0-23 scale); National Health interview survey Results: Immediate post tx (10 wks): Pain: 4.0 vs. 3.6 vs. 4.6 Disability: 7.9 vs. 6.3 vs. 8.8 Short term : NA Intermediate: NR Long term (1 yr): Pain, mean: 5.4 vs. 3.2 vs. 3.8 Disability: 8.0 vs. 6.8 vs. 6.4 | Outcome instruments: QoL/ well being: SF-12, Mental Health summary scales Other: %pts using Med at 10 wks fu: from 69% to 51% in acu vs. from 73% to 47% in massage group, and little change in self care group Short term: NR Intermediate: NR Long term: NR Harms: No SAEs, or WDAE Summary: At 1 yr no significant difference in % of pts with recurrence of BP in last 6 mo (80%), seeking back care (40%) or visiting an acu tx (15%)
Field T (2007)172 Country: Miami, US Quality score: 2/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: Two sessions Final assessments: immediately post tx N screened: 30 N randomized: 30 N completed tx: 30 N attended last fu: NR Inclusion: Adults with LBP of a duration of at least 6 mo; cleared by their primary physician to participate in the study Exclusion: BP due to fractured vertebrae, herniated or gegenerated disks, pts who had undergone surgery for their back pain (i.e. laminectomies or fusions) and pts with sciatic nerve involvement or legal action pending, such as workmen's compensation | Mean age (SD/range): 41 yrs % of male: 53% Racial composition: 67% Caucasian Work status: NR Other socio-demographics: Group avg =middle class; M=2.5 on Hollingshead Index Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Chronic, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 15)– Massage therapy: kneeding, rubbing, stroking along entire back and legs; two 30 min sessions/ wk Drop outs: NR CG (n = 15) – Relaxation therapy: PTS were shown how to use progressive MR EXs including tensing and relaxing large muscle groups starting with the feet and progressing to the calves, thighs, hands, arms, back and face; two 30 min sessions at home/ wk Drop outs: NR | Outcomes: Pain: VAS (10 cm) Disability: Trunk flx (cm); pain flx (cm) – higher scores optimal Results: Baseline: Pain: IG = 5.1 (2.9), CG = 4.4 (2.1) Disability: IG = 58.9 (7.5), CG = 59.1 (7.9); IG = 61.6 (8.1), CG = 61.1 (7.6) Immediate post tx: Pain: IG = 1.4 (1.6), CG = 2.7 (2.4) Disability: IG = 61.9 (8), CG = 60.7 (4.7); IG = 63.5 (8.1), CG = 63.6 (4) Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR
Franke (2000)173 Country: Germany Quality score: 8/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: NR Final assessments: immediately post tx N screened: 190 N randomized: 190 N completed tx: 179 N attended last fu: 179 Inclusion: 25-55 yrs old, chronic BP> 1 yr, German speaking Exclusion: neurological deficits, neurosis, psychosis, Med for >3 ds, therapy interruption for >5 ds, people applying for early retirement due to disability, people unable to work > 4 wks before rehab or >3 mos in previous yr | Mean age (SD/range): IG1 = 45.2 (8), IG2 = 43.5 (9), IG3 = 45.6 (7.5), CG = 44.4 (8) yrs % of male: All Grps : 61% Racial composition: NR Work status: NA Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Degenerative Disease Duration of Pain: > 1 yr Severity of pain (Grading): VAS: IG1 = 5.4 (2.6), IG2 = 4.2 (2.4), IG3 = 4 (2.2), CG = 4.4 (2.2), Flexion lumbar spine IG1 = 46.4 (15.6), IG2 = 49.4 (12.4), IG3 = 52.8, CG = 49.1 (13.1), Extension lumbar spine IG1 = 12.9 (6.4), IG2 = 13.6 (6.6), IG3 = 14.8 (7), CG = 12.2 (6.6) Co-interventions: NR | Groups IG1 (n = 46)– Acupuncture massage of entire meridians+ group EX (GE): 12-16 sessions each 30min Drop outs: 1 IG2 (n = 49)– Swedish Massage (SM) + GE 30 min/ session, 8-10 sessions In gym and 4-6 session in pool Drop outs: 3 IG3 (n = 46)– Acupuncture massage + individual medical EX (IE) 30 min/ session, 4 sessions Drop outs: 5 CG (n = 49) – SM + IE 15 min/ session for 8 sessions Drop outs: 2 | Outcome instruments: Pain: VAS, flx & ext Disability: Functional Questionnaire Hanover (FFbH) Results: Baseline: Pain: IG1 = 5.4 (2.6), IG2 = 4.2 (2.4), IG3 = 4 (2.2), CG = 4.4 (2.2) Disability: 86 (18) for all pts Immediate post tx: Pain: Mean: IG1 = -1.83, IG2 = -1.00, IG3 = -1.46, CG = -0.62 Disability, change from baseline APM vs. SM: 7.0% (95% CI: 2.5, 11.6) Short term: NR Intermediate: NR Long term: NR | QoL/ well being: NR Results-mean: NR Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: results with APM are promising, warrant further investigation, no superiority individual vs. grp EXs
Geisser, M (2005)174 Country: Michigan, US Quality score: 3/13 Initial of reviewer: SG | Trial Design- RCT Tx duration: 5 wks Final assessments: post tx N screened: 100 N randomized: 100 N completed tx: NR N attended last fu: NR Inclusion: 18-65 yrs with single or primary complaint of CLBP and judged to have musculoskeletal pain based on evaluation by the physician or physical therapist Exclusion: Down's syndrome, osteoporosis of the spine, agenesis of the odontoid process, primary joint disease (active rheumatoid arthritis), metabolic bone disease, malignant bone disease, fracture, hypermobility of the lumbar/sacral spine, cardiovascular or other medical disorders | Mean age (range): 37 - 46 yrs % of male: 34 (avg of all grps) Racial composition: 85 Caucasian, 8 African-Am, 5 Asian-Amer., 2 Hispanic Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Chronic, 76.9 mo Severity of pain (Grading): NR Co-interventions: NR | Groups IG1 (n = 26) – Manual therapy, S EX:; 5 wkly EXs for 20 min, stretching twice daily (10 reps, hold for 30 sec each) Drop outs: NR IG2 (n = 25) –Sham therapy, S EX: Same as IG but MET not performed; same as IG1 Drop outs: NR IG3 (n = 24) –manual therapy, nonS EXs: pts free to choose how to perform aerobic EX; same as IG1 Drop outs: NR IG4 (n = 25) – Sham therapy, N-S EX: same as IG3; same as IG1 Drop outs: NR | Outcomes: Pain: VAS (0-10); MPQ (0-78) Disability: Quebec Back Pain Disability Scale (QBPDS) (0-100) Results- Immediate post tx: Pain-mean change: VAS: IG1 = -2.05, IG2 = -0.38, IG3 = -0.52, IG4 = -0.91 MPQ: IG1 = -9.39, IG2 = -4, IG3 = -2.47, IG4 = -1.28 QBPDS-mean change: IG1 = -5, IG2 = -0.97, IG3 = -6.67, IG4 = -8.58 Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Results: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: Pts in IG1 displayed significant improvements in pain. No significant changes in disability were observed with the exception that the IG2 displayed a significant increase in disability
Hernandez-Reif M (2001)175 Country: US Quality score: 2/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 5 wks Final assessments: immediately post tx N screened: NR N randomized: 24 N completed tx: 24 N attended last fu: post tx Inclusion: adults with LBP with a duration of at least 6 mos Exclusion: BP due to fractured vertebrae herniated or degenerated disks, pts who had undergone surgery for their back pain, and pts with sciatic nerve involvement or legal action pending, such as workmen's compensation. | Mean age (SD/range): IG = 43.8 (13.7) vs. CG = 36.7 (16.1) yrs % of male: IG = 41.6%, CG = 50% Racial composition: 66.7% Caucasian Work status: NR Other socio-demographics: 37.4% Middle class Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: N-S Duration of Pain: Chronic, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 12) – Massage therapy: stroking, kneeding, rubbing applied to the entire back at a level tolerant to the pt and to legs; two 30 min sessions/wk over 5 wks Drop outs: NR CG (n = 12) – Relaxation: instructed on progressive MR exercices tensing and relaxing large muscle groups starting with the feet and progressing to the calves, thighs, hands, arms, back and face; 30 min/ session at home, twice/wk for 5 wks Drop outs: NR | Outcomes: Pain: SF-MPQ; VAS (0-10) Disability: Results: Baseline: Pain: MPQ: IG = 16.5 (8.2), CG = 16.7 (7.5) VAS: IG = 5.62 (2.2), CG = 4.5 (1.9) Disability: NR Immediate post tx: Pain: MPQ: IG = 4.1 (4.9) CG = 6.4 (6.4) VAS: IG = 1.7 (2.3), CG = 2.9 (2.8) Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Other: ROM: Trunk flx; pain flx (cm) Results: Baseline: IG = 56 (7.4), CG = 57.5 (7.9); IG = 57.7 (8), CG = 61.1 (7.6) Immediate post tx: IG = 61.4 (7.4), CG = 58.2 (3.6); IG = 61.3 (9.1), CG = 60.6 (3.9) Short term: NR Intermediate: NR Long term: NR Harms: NR Note: massage group had less pain, depression, anxiety and had improved sleep
Hsieh LLC (2006)176 Country: Taiwan Quality score: 9/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 1 mo Final assessments: 6 mos N screened: 188 N randomized: 129 N completed tx: 129 N attended last fu: 129 Inclusion: Pts aged > 18 yrs with CLBP (> 4 mo) Exclusion: cancer, systemic diseases, psychiatric disorders, pregnancy, acute severe pain in need of surgery or immediate tx, contraindication to acupressure | Mean age (SD/range): IG = 50.2 (13.8) vs. CG = 52.6 (17.2) yrs % of male: IG = 33%, CG = 26% Racial composition: NR Work status: NR Other socio-demographics: Married: 83.5% Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: N-S Duration of Pain: Chronic, median (range) IG = 3.3 (0.2-33.3) yrs, CG = 1.6 (0.2-34.3) yrs Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 64)– Acupressure: NR; 6 sessions in 1 mo Drop outs: D = 9 CG (n = 65) – PT: pelvic manual traction, SM, thermotherapy, infrared light therapy, ES, and EX; same as IG Drop outs: D = 11 | Outcome instruments: Pain: Core outcome measure-LBP;VAS-ITT Disability: RMDQ; Modified Oswestry Results- Immediate post tx: Pain: IG = 2.11 (0.86), CG = 2.57 (0.83); IG = 30.6 (21.75), CG = 48 (23.4) Disability: IG = 5.4 (5), CG = 9.2 (5.8) IG = 17 (7.6), CG = 20.6 (8.8) Intermediate: Pain: IG = 1.59 (0.73), CG = 2.17 (0.89); IG = 16.1 (17.4), CG = 41.4 (24.6) Disability: IG = 2.2 (3.2), CG = 6.7 (5.5); IG = 12.2 (4.9), CG = 17.9 (8.1) | Outcome instruments: QoL/ well being: NR Other: pts with significant degree of disability (no.) Baseline: 28 vs. 20 Post tx: 8 vs. 19 Intermediate: 1 vs. 8 Long term: NR Harms: NR
Hsieh, L (2007)177 Country: Taiwan Quality score: 9/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 4 wks Final assessments: 6 mos N screened: 220 N randomized: 146 N completed tx: 146 N attended last fu: 121 Inclusion: 16 - 84 yrs with CLBP Exclusion: LBP caused by severe systematic diseases (SLE or rheumatoid disease); contraindications to acupressure and physical therapy; cancer, pyschiatric disease with the presence of overt clinical symptoms before participation; severe pain (pain score >90%), surgical operation prescribed by a physician as tx for LBP | Mean age (SD/range): IG = 47.6 (13.6) vs. CG = 47.6 (14.9) yrs % of male: IG = 43.4%, CG = 51.9% Racial composition: NR Work status: 27.5% Householder Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: N-S Duration of Pain: Chronic (1 mo – over 10 yrs) Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 69) – Acupressure: no description given; 6 session over 4 wk period, 15 min/ tx Drop outs: A = 4, B = 0, D = 13 CG (n = 77) – Physical therapy: followed the routine practice of the hospital. Included pelvic manual traction, thermotherapy, infrared light therapy, ES, and EX therapy, as decided by one senior physical therapist; same as IG Drop outs: A = 5, B = 0, D = 12 | Outcomes: Pain: Pain visual scale (0-5)- SF-PQ Results: Baseline: Pain: IG = 1.95 (2.96), CG = 2.23 (3.33); NR Immediate post tx: Pain: NR; IG = 2.28 (2.62), CG = 5.05 (5.11) Short term: NR Intermediate: NR; IG = 1.08 (1.43), CG = 3.15 (3.62) Long term: NR | Outcome instruments: QoL/ well being: NR Other: NA Results: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: No AEs were reported in the acupressure group
Little, P (2008)178 Country: UK Quality score: 8/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 4/6 wks, 5 mos Final assessments: 1 yr N screened: 1027 N randomized: 579 N completed tx: NR N attended last fu: 464 Inclusion: significant recurrent or CLBP, presenting to primsry care with LBP > 3 mo (to exclude 1 st episode), currently scoreing ≥ 4 on Roland disability scale, current pain for ≥ 3 wks ( Exclusion: previous experience of Alexander techniques (AT); pts under 18 or over 65; serious spinal disease; current nerve root pain (below knee in dermatomal distribution), previous spinal surgery, pending litigation; history of psychosis or major alcohol misuse | Mean age (SD): IG1 = 46 (10), IG2 = 45 (11), IG3 = 45 (11), IG4 = 46 (10) yrs % of male: 30.5 Racial composition: NR Work status: 74.5% Employed Other socio-demographics: 59.2% Married Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Chronic (> 3 mo) or recurrent (last episode > 3 wks in duration) Severity of pain (Grading): ≥ 4 on Roland disability scale Co-interventions: NR | Groups IG 1a (n = 75) Massage 1b – massage + EX, (n = 72); 6 sessions, 1 session/ wk for 6 wks, EX at 6 wks Drop outs: C = 29, E = 27 IG (n = 144) 2a – 6 Alexander technique lessons;; 6 lessons, 4 wks Drop outs: C = 21, E = 29 IG (n = 144) 3a – 24 Alexander lessons; in 5 mo Drop outs: C = 29, E= 27 IG (n = 144) 4a – Usual care + EX; started EX tx at 6 wks Drop outs: C = 36, E = 33 | Outcome instruments: Pain: Median ds with no pain (IQR) Disability: Roland disability score Results: Baseline: Pain: IG1 = 28 (14-28), IG2 = 28 (8-28), IG3 = 28 (13-28), IG4 = 24.5 (14-28) Disability: NR Immediate post tx: Pain: NR Disability: Short term: changecompared to control from baseline RDS: -1.90 vs. -1.71 vs. -2.91 Intermediate: NR Long term: \ Number of ds with LBP was lower after lessons and QoL improved also. | Outcome instruments: QoL/ well being: NR Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: worse pain by one pts no group designation reported
Mackawan S (2007)145 Country: Thailand Quality score: 5/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: one session Final assessments: post-tx N screened: NR N randomized: 67 N completed tx: 67 N attended last fu: 67 Inclusion: 20-60 yrs; persistent CLBP (> 12 wks); no evidence of underlying diseases or anatomical abnormalities Exclusion: menstruation; pregnancy; body temp 38.5°C on d of exam.; a history of acute trauma, back surgery, spinal fracture, joint subluxation or instability, inflammatory joint disease muscle disease, malignancy or infection; evidence of neurologic deficits, multiple sclerosis, hemi/para paresis or myelopathy, skin diseases, or infectious diseases | Mean age (SD/range): IG = 38.97 (7.85) vs. CG = 38.57 (7.66) yrs % of male: IG = 34%, CG = 44% Racial composition: NR Work status: Government service= 49% Private officer= 32.5%; Student= 6%; Business owner = 11.5% Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Chronic, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 35)– Traditional Thai massage(TTM): Deep massage with prolonged pressure (5-10s/point) on the muscles along with passive stretching. Gentle stretching of the joints and muscles relieves tension, enhances flexibility, and induces a deep state of tranquility; one 10 min session Drop outs: NR CG (n = 32) – Joint Mob: Spinal Mob is a passive movement of a spinal segment with and occasionally beyond its active ROM.; as IG Drop outs: NR | Outcomes: Pain: VAS (10 cm); substance p levels in saliva Results: Baseline: Pain: IG = 4.22 (1.98), CG = 4.35 (1.71); IG = 73.86 (62.31), CG = 80.61 (85.26) Immediate post tx: Pain: IG = 2.45 (1.75), CG = 3.39 (1.66); IG = 50.43 (64.39), CG = 56.27 (72.77) Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Results: NA Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR
Poole, H (2007)179 Country: UK Quality score: 5/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 6-8 wks Final assessments: 6 mos N screened: 650 N randomized: 234 N completed tx: 191 N attended last fu: 156 Inclusion: 18 - 65 yrs with benign CLBP Exclusion: pregnancy, significantly co-existing major medical illness, diagnosis with a significant co-existing psychiatric disorder and under the care of a psychiatric services; in litigation; previous use of reflexology and contraindication to reflexology including: recent surgery and circulatory disorders of the lower limb | Mean age (SD/range): IG = 47.2 (10.5), CG1 = 45.6 (12), CG2 = 47.25 (10.2) yrs % of male: IG = 37.6, CG1 = 35.4, CG2 = 49.3 Racial composition: NR Work status: 50% Employed Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: N-S Duration of Pain: Chronic, IG = 120.6 (114.5) mo; CG1 = 128.4 (104.5) mo; CG2 = 114.7 (106.7) mo Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 77)– Reflexology: Morrell technique. No standardised protocol was provided, reflexologists were advised to treat pts CLBP as per their standard practice; 6 tx of 1 hr/wk over 6-8 wks Drop outs: A = 9, B = 13, D = 8 CG1 (n = 82) – Relaxation: Progressive MR; 6 tx of 1 hr/wk over 6 wks in groups of 1 - 4 Drop outs: A = 13, B = 12, D = 3 CG2 (n = 75) – Non-intervention: Continue regular visits to GP Drop outs: A = 21, B = 11, D = increase of 2 pts | Outcomes: Pain: SF-36- pain component (0-100); VAS (0-100) Disability: ODQ Results: Immediate post tx: Pain VAS: 39.8 (29.2) vs. 41.3 (28.5) vs. 42.7 (28.4) Disability: 29 (20.2), CG1 = 31.3 (21.1), CG2 = 32.9 (17.6); Short term: NR Intermediate: Pain: 39.8 (29.2) vs. 41.3 (28.5) vs. 42.7 (28.4) Disability: No change Long term: NR | Outcomes: QoL/ well being: Back depression inventory- 21 items, 4 pt scale (0-3) Immediate post tx: IG = 11 (10.2), CG1 = 12.9 (11.7), CG2 = 14.4 (10.5) Short term: NR Intermediate: IG = 11.6 (10.9), CG1 = 12.6 (10.9), CG2 = 12.8 (9.2) Pts not using any tx at the end of trial: 31 vs. 21 vs. 13 Harms: NR Note: adding reflexology to GP was not more effective than usual GP alone
Quinn, F (2008)180 Country: UK Quality score: 9/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 6 wks Final assessments: 3 mos N screened: 15 N randomized: 15 N completed tx: 15 N attended last fu: 15 Inclusion: Staff employed at the U of Ulster with N-S LBP, any phisiotherapy, Med or other tx for LBP has been stabilized for at least 3 mos, no involvement in other research projects within past 3 mos, reflexology naïve (with no detailed knowledge of S reflexology points), not pregnant. Exclusion: NR | Mean age:43 yrs % of male: IG = 14.3%, CG = 50% Racial composition: NR Work status: All employees of University of Ulster Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: N-S Duration of Pain: NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 7) – Reflexology: Reflexology on key points of the feet that are representative of the vertabrae of the spine and the surrounding musculature (inner edge of both feet); 40 min/ wk for 6 wks Drop outs: 1 pt received only 4 tx CG (n = 8) – Sham (foot massage): simple foot massage using same sequences as in the reflexology tx group but less pressure, points representative of the vertabrae of the spine and surrounding musculatire were avoided; same as IG Drop outs: None | Outcomes: Pain: VAS (10 cm); McGill Pain (0-77); SF-36 (bodily Pain measure)- ITT Disability: RMDQ Results: Immediate post tx: Pain: IG = 3.1, CG = 3.9; IG = 46.1 (5.2), CG = 41.8 (9.6) Disability: IG = 6 (1.8), CG = 5 (2.6); Short term: Pain: IG = 2.2 (1.2), CG = 3.2 (1.5) IG = 11 (8.1), CG = 6.5 (1.6); IG = 51.1 (6.7), CG = 46.1 (0.7) Disability: IG = 4 (2.2), CG = 3.5 (2.2) Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Other: Physical functioning SF-36- (0-100) Immediate post tx: NA IG = 48.6 (2.2), CG = 43.4 (7.4) Short term: NR IG = 48.6 (2.2), CG = 44.4 (3) Intermediate: NR Long term: NR Harms: no AEs reported in any of the grps throughout the tx period
Zaproudina, N (2009)181 Country: Kuopio, Finland Quality score: 5/13 Initial of reviewer: SG | Trial Design- RCT Tx duration: not clear Final assessments: 12 mos N screened: 221 N randomized: 122 N completed tx: NR N attended last fu: NR Inclusion: CLBP with or without referred leg pain; minimal VAS of 30 and/or Oswestery Disability Index of at least 16% Exclusion: Pregnancy; rheumatic or other disease; severe structural deformity; back operation; acute disk herniation; severe sciatica; receiving any therapy during previous mo | Mean age (SD/range): IG = 41.7 (5.8) vs. CG = 40.7 (5.3) yrs % of male: IG = 51%, CG = 47% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: Chronic, NR Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 63)– Physical and EX therapy: massage, therapeutic stretching and EX therapy; individual EX programs for home training and ergonomic instructions; timetable and kind of tx freely chosen by physiotherapist; 5 sessions Drop outs: A=3,B=1 CG (n = 59) – Traditional bone setting; NR; 3-5 sessions, 90 min/session, 1 or 2 wk intervals Drop outs: A=5,B=3 | Outcomes: Pain: VAS (0-100) Disability: Oswestry Disbility Index (ODI) (0-100) Results: Baseline: Pain: IG = 40.8 (20.9), CG = 40.9 (22.9) Disability: IG = 21.5 (8.3), CG = 19.9 (9.7) Immediate post tx: Pain: ---- Disability: ---- Short term: VAS: IG = 26.8 (20.3), CG = 21.8 (24.5) ODI: IG = 16.3 (9.9) CG = 12.2 (11) Intermediate: no numeric data reported Long term: no numeric data | Outcome instruments: QoL/ well being: NR Other: NA Results: Baseline: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: worsening of pain (WDAE), 2 vs. 1

Table 1.39 Low Back Pain - Massage - Mixed - Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Zhang, J (2004)182 Country: China Quality score: 6/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 3-6 wks? Final assessments: post tx N screened: 165 N randomized: 165 N completed tx: 165 N attended last fu: NR Inclusion: diagnosed as Shanghai Chinese Medical Diagnostic and therapeutic Effective Standard, score between 0-23 based on Lumbar Function Assessment (ref[5]), 20-60 yr, no other tx before, volunteer participation Exclusion: pregnant, brest feeding, with fracture, tumor, low bone density, skin damage, tubercal | Mean age (SD/range): IG = 40.9 (10.5), CG1 = 41.2 (10.8), CG2 = 42.1 (10.5) yrs % of male: 57% Racial composition: Most likely Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc/joint disease: lumbar disc herniation Duration of Pain: Acute, Sub-acute and chronic, IG = 6.8 (2.3), CG1 = 6.9 (2.3), CG2 = 6.8 (2.4) mo Severity of pain (Grading): NR Co-interventions: NR | Groups CG (n = 55)– Traction: traction table, 0.5 weight-weight, 20 min/tx; 1 tx/d, 20 tx total Drop outs: A = NR, B = 0 IG (n = 55) – Massage: NR; 20 min/ tx; 3 tx/wk, 20 tx total Drop outs: A = NR, B = 0 IG2 (n = 55) – Massage + EX: Massage: 20 min/tx, 3 tx/wk 20 tx total. Exercise: 20-30 min/tx, 3 tx/wk Drop outs: A = NR, B = 0 | Outcomes: Pain: Score based on Shanghai Chinese Mediccal diagnosis and treament Standard Procedure Results: Baseline: Pain: CG= 12.78 (1.68), IG1 = 12.75 (1.65), IG2 = 12.79 (1.67) Immediate post tx: Pain: CG= 17.87 (7.51), IG1 = 25.71 (4.95), IG2 = 25.83 (5.02) Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Other: marked effect of tx Results : Immediate post tx: The markedly effective rate in IG1 was no diff. than IG2 but the rate for IG was better than CG (t = 2.4, p < 0.05) Short term: NR Intermediate: NR Long term: NR Harms: NR

Table 1.40 Low Back Pain - Massage - Mixed - Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Chatchawan U (2005)183 Country: Thailand Quality score: 6/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 3-4 wks Final assessments: 3 wks and 1 mo post tx N screened: 214 N randomized: 180 N completed tx: 177 N attended last fu: 172 Inclusion: 21-50 yrs; persistent LBP; >/= one TP was present in the upper and/or lower torso region (TP = presence of focal tenderness at a palpable nodule in a taut band + pain recognition) Exclusion: menstruation; pregnancy; fever; a hx of acute trauma, back surgery, spinal fracture, other significant disorders of musckuloskeletal or nerveous system | Mean age (SD/range): IG = 37.3 (8.8) vs. CG = 35.5 (8.8) yrs % of male: 36% Racial composition: NR Work status: 95% Light workers Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: IG = 6.7 (8.1) wks; CG = 5.2 (5) wks Prior CAM intervention: NR Prior surgery related to current complaint: None | Cause of Pain: Myofacial pain syndrome Duration of Pain: Sub-acute/chronic, IG = 36.6 (38.8) mo; CG = 34.8 (35.6) mo Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 90)– Traditional Thai massage (TTM); 6 sessions over a 3-4 wks, generally 2 sessions/wk for 3 wks Drop outs: A = 1, B = 0, C = 4 CG (n = 90) – Swedish Massage (SM): performed using body-oil for lubrication for the skin; Same as IG Drop outs: A = 1, B = 1, C = 1 | Outcomes: Pain: VAS (10 cm) N based on ITT Disability: ODQ Results-Baseline: Pain: IG = 5.5 (1.5), CG = 5.2 (1.7) Disability: IG = 20.7 (8.9), CG = 20.7 (8.3) Immediate post tx: Pain: IG = 2.2 (1.9), CG = 2 (1.7) Disability: IG = 13.8 (8.8), CG = 15.4 (9.1) Short term: VAS: IG = 2.4 (1.9), CG = 2.5 (2) ODQ: IG = 13.4 (10.1), CG = 13.9 (8.9) Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: NR Other: Back performance (data not shown) Results: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: one Pt in IG droped out due to car accident
Hoehler F (1981)134 Country: US Quality score: 3/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: NR Final assessments: immediately post tx; and long term (as stated in the study) N screened: 1880 N randomized: 95 N completed tx: NR N attended last fu: NR Inclusion: presence of palpatory cues indicating that SM might be successful Exclusion: Spinal manipulation contraindicated or alternative tx strongly indicated; pregnancy; previous experience with manipulation; disability income; pending litigation; previous back surgery; obesity; drug or alcohol abuse | Mean age (SD/range): IG = 30.1 (8.4) vs. CG = 32.1 (9.8) yrs % of male: 59% total Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: N-S Duration of Pain: 50% Acute, 23% Chronic Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 58)– Manipulation: rotal manipulations of the lumbosacral spine; # of tx varied Drop outs: NR CG (n = 39) – Soft-tissue massage: soft-tissue massage of the lumbosacral areas, with the rotal thrust omitted; same as IG Drop outs: NR | Outcome instruments: Pain: improvement in amout of pain Disability: NR Results: Immediate post tx: % of Pts with improved pain: 84% vs. 68% Disability: NR Short term: NR Intermediate: NR Long term: Pts reporting tx as effective: 88% vs. 86%) | Outcome instruments: QoL/ well being: NR Improvement in SLR, degrees: Results: Immediate post tx: To pelvic rot 1.6 (6.3) vs. 1.0 (6.3) To pain: 3.3 (6.2) vs. – 0.5 (5.9) Short term: NR Intermediate: NR Long term: SLR to pelvic rot 8.0 (9.3) vs. 4.1 (8.6); to pain: 7.8 (7.4) vs. 8.6 (8.4) Improvement in forward flextion (cm): 11.4 (15.9) vs. 10.7 (14.2) Harms: NR
Zhang, J (2004)182 Country: China Quality score: 6/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 3-6 wks? Final assessments: immediately post tx N screened: 165 N randomized: 165 N completed tx: 165 N attended last fu: NR Inclusion: diagnosed as Shanghai Chinese Medical Diagnostic and therapeutic Effective Standard, score between 0-23 based on Lumbar Function Assessment (ref[5]), 20-60 yr, no other tx before, volunteer participation Exclusion: pregnant, brest feeding, with fracture, tumor, low bone density, skin damage, tubercal | Mean age (SD/range): IG = 40.9 (10.5), CG1 = 41.2 (10.8), CG2 = 42.1 (10.5) yrs % of male: 57% Racial composition: Most likely Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc/joint disease: lumbar disc herniation Duration of Pain: Acute, Sub-acute and chronic, IG = 6.8 (2.3), CG1 = 6.9 (2.3), CG2 = 6.8 (2.4) mo Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 55)– Traction: traction table, 0.5 weight-weight, 20 min/tx; 1 tx/d, 20 tx total Drop outs: A = NR, B = 0 CG1 (n = 55) – Massage: NR; 20 min/ tx; 3 tx/wk, 20 tx total Drop outs: A = NR, B = 0 CG2 (n = 55) – Massage + EX: Massage: 20 min/tx, 3 tx/wk 20 tx total. Exercise: 20-30 min/tx, 3 tx/wk Drop outs: A = NR, B = 0 | Outcomes: Pain: Score based on Shanghai Chinese Mediccal diagnosis and treament Standard Procedure Results: Baseline: Pain: IG = 12.78 (1.68), CG1 = 12.75 (1.65), CG2 = 12.79 (1.67) Immediate post tx: Pain: IG = 17.87 (7.51), CG1 = 25.71 (4.95), CG2 = 25.83 (5.02) Short term: NR Intermediate: NR Long term: NR | Outcome instruments: QoL/ well being: Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR

Table 1.41 Low Back Pain - Massage - Unknown - Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Li, ZY (2006)184 Country: China Quality score: 10/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: NR Final assessments: post-tx N screened: 60 N randomized: 60 N completed tx: 60 N attended last fu: 60 Inclusion: Typical symptoms; Clinical positive signs; Diagnosed by CT or MRI; aged 20-55 yrs Exclusion: Severe lumbar trauma; History of lumbar surgery; Lumbar spine bone destruction; Central nervous symptoms; Serious visceral disease | Mean age (SD/range): IG = 46.17(2.99) vs. CG = 44.67 (3.23) yrs % of male: IG = 53.8%; CG = 53.3% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Cause of Pain: Disc herniation Duration of Pain: Cannot tell Severity of pain (Grading): NR Co-interventions: NR | Groups IG (n = 30) – Living acupoint tx: massage at acupoint; NR Drop outs: A=0;B=0 CG (n = 30) – Oblique-pulling: SM, oblique-pulling on the pt’s lumbar vertebra; NR Drop outs: A=0;B=0 | Outcomes: Pain: score evaluation of pain; VAS Results: Baseline: Pain: IG = 40.6 (2.93), CG = 42.83 (3.63) IG = 8.99 (0.26), CG = 8.94 (0.27) Immediate post tx: Pain: IG = 64.77 (4.14), CG = 60.7 (5.78) IG = 4.71 (0.52), CG = 5.59 (0.8) Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Results: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR

Outcomes: ODQ=Oswestry disability questionnaire; RMQ=Roland Morris Questionnaire; NPQ=Northwick Neck Pain Questionnaire; MPQ=McGill Pain Questionnaire; ODI=Oswestry Disability Index; NDI=Neck Disability Index; NHP=Nottingham Health Profile; HFAC=Hanover Functional Ability Questionnaire PDI=pain disability index; GWBS=global well-being scale; SLR=straight leg raising; GPE=global perceived effect; FTF=finger-to-floor; PPI=present pain intensity; PRI=pain rating index; PUP=pain under pressure; MRP=motion related pain; NPAD=Neck Pain and Disability Scale; QoL=Quality of Life; MVEE=maximum voluntary extension effort; PQ=pain questionnaire; MPQ=Short Form McGill Pain Questionnaire; RMAS=Roland Morris Activity Scale; QBPDS=Quebec Back Pain Disability Scale; mRDQ=modified Roland Morris Questionnarie NRS=numeric pain rating scale; PPT= pressure pain VAS=visual analogue scale;; SF= short form threshold; Special terms: HVLA=high velocity low amplitude; ETOIMS=electrical twitch-obtaining intramuscular stimulation; IMS=intramuscular stimulation; FDT=flexion distraction technique; TrP=trigger point; GP=general practitioner; CAM =complementary and alternative medicine; NSAIDs=non-steroidal anti-inflammatory drugs; NP=neck pain; N-S=non-specific; S=specific; Med=medication; PT= physiotherapy; ST=standard therapy; E-acu=electro acupuncture; MR= muscle relaxation; EX=exercise CLBP=chronic low back pain; A=baseline evaluation; B=immediately post treatment; C= short term follow up (up to 3 months post treatment); D=intermediate follow up (up to 6 months post treatment); E=long term follow up (over 6 months post treatment); acu=acupuncture; SM=spinal manipulation; LBP= low back pain; NP=neck pain; TP=thoracic pain TENS/TNS= transcutaneous electrical nerve stimulation; ROM=range of motion; MPS=myofascial pain syndrome; Mob=mobilization; ext=extension; flx=flexion; rot=rotation; MS=MS; PM=physical modalities; mA=milli Amp; Statistical: NS=statistically non-significant; SD=standard deviation; SE=standard error; WMD=weighted mean difference ; p=p-value; 95% CI= 95% Confidence Interval; SS= statistically significant; General terms: NA=not available/applicable; NR=not reported; Pt(s)=patient(s); d=day(s); mo(s)=month(s); yr(s)=year(s); wk(s)=week(s); N=number NS= not significant; pt/s= patient/s; tx=treatment/intervention Fu=follow up; ITT=intention to treat; IG=intervention group; CG=control group; RCT=randomized controlled trial; AE(s)=adverse event(s); SAE= serious adverse events; WDAE= withdrawal due to adverse events

## Neck Pain

Table 2.1 Neck Pain - Acupuncture - Acute - Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other outcomes; Harms
Aigner, N (1999)185 Country: Austria Quality score: 6/13 Initial of reviewer: SG | Trial Design RCT Tx duration: NR Fu duration (last assessment): NR N screened: 84 N randomized: 84 N completed tx: NR N attended last fu: NR Inclusion: whiplash for no longer than 4 ds. 18 – 65 yrs old Exclusion: fresh traumatic bone fractures near cervical spine, massive neurological symptoms, pts with small degree of injury | Mean age (SD/range):NR % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: Cervical spine Cause of Pain: NR Duration of Pain, mean (SD/range): Acute, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 28) – cervical collar, Chlormezanon, Paracetamol + Verum Acupuncture: AP points T.B.5 (Wai Kuan), S.I.6 (Yang Ku) needled on both sides, propagated sensation along the channel, paresthesia along the meridians; NR Drop outs: NR IG (n = 23) – cervical collar, Chlormezanon, Paracetamol + laser acu: low level laser therapy; NR Drop outs: NR CG (n = 33) – Chlormezanon, Paracetamol and cervical collar: NR; NR Drop outs: NR | Outcomes (describe instrument used): Pain: data presented in bar graphs – not shown here. Disability: NA Results: Baseline: Pain: NA Disability: NA Immediate post tx: Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: Short term: NR Intermediate: NR Long term: NA Harms: NR Summary: sig improvement in IG in reduction in duration of pain and sick leave

Table 2.2 Neck Pain - Acupuncture - Acute - Non –Specific Pain - No Studies

Table 2.3 Neck Pain - Acupuncture - Chronic - Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other outcomes; Harms
Birch S (1998)190 Country: US Quality score: 2/13 Initial of reviewer: SG | Trial Design: RCT Tx duration: 12 wks Fu duration (last assessment): 6 mos N screened: 59 N randomized: 46 N completed tx: 46 N attended last fu: 36 Inclusion: Chronic myofascial NP (> 6 mo), identifiable painful area with hightened sensitivity to moderate touch; unsuccessful response to PT (traction, heat, US, massage) Exclusion: disc herniation, cervical osteoarthritis, infection, malignancy, collapsed vertebra, collagen-vascular disease, brachial plexopathy, schizophrenia, delusional, psychotic, or bipolar disorder | Mean age (SD/range): IG1 = 40.9, IG2 = 38, CG = 38.6 yrs % of male: IG1 = 14.3%, IG2 = 23%, CG = 14.3% Racial composition: NR Work status: NR Other socio-demographics: 33.6% married Co morbidities: NR Prior episode of pain if acute: accident related injury: 33.6% Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: Cause of Pain: S, NR Duration of Pain, mean (SD/range): Chronic, IG = 81.9 mo, IG2 = 92.2 mo, CG = 91.1 mo Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: 500 mg/d NSAIDs | IG1 (n = 15) – Acu-relevant: 1) gauge 2 (0.18) mm) shallow needling in points 9SI3, BL62, GB41, TW5 to 2-3 mm in depth, needles connected to IP cords and left in place for 10 min. 2) needling done in neck, shoulder, upper back in left/right, then heat applied for 10 min; 14 tx, 12 wks Drop outs: D = 4 IG2 (n = 16) – Acu-irrelevant: shallow needling with gauge 2 (0.18 mm) bilaterally to 2-3 mm depth in hands and feet at LI5, GB42, TW8, ST41, needles connected by cords as like IG1, left for 10 min, points BL16, SI9, LI15 needled bilaterally by 6 needles to 2-3 mm depth; Same as IG1 Drop outs: D = 3 CG (n = 15) Medication: NSAIDs; 12 wks Drop outs: D = 3 | Outcomes: Pain: SF-MPQ (no numerical data given); Pain intensity rating (1-10) Results: Baseline: Pain: IG1 = 4.8, IG2 = 4.7, CG = 4.9 Immediate post tx: Pain: IG1 = 1.58 (1.9), IG2 = 3.37 (2.14), CG = 4.76 (2.05) Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR
Ceccherelli F (2006) 194 Country: Italy Quality score: 6/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 8 wks Fu duration (last assessment): 6 mos N screened: NR N randomized: 62 N completed tx: 62 N attended last fu: 62 Inclusion: Myofascial cervical pain Exclusion: fibromyalgia, severe systemic illness (asthma, emphisema, chronic bronchitis, severe myocardial failure, hypertensive tx with reserpine/clonidine, osteoporosis, tranquilizers, drug/alcohol use, peripheral or central neurological illness (MS, epilepsy, brain injury, diabetes), adipose panniculus | Mean age (SD/range): IG = 45.5 (10.28) vs. CG = 39.8 (9.01) yrs % of male: 26% total sample Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: S, NR Duration of Pain, mean (SD/range): Chronic, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: 1 g paracetamol permitted in acute pain episodes | Groups IG (n = 31)– somatic Acupuncture; at 3 SI (Houxi), 5 TE (Waiguan), 4 LI (Hegu), 10 BL (Tianzhu), 20 GB (Fengchi) embedded bilaterally; points 14 GV (Dazhui) and 15 GV (Yamen) embedded only in the median line. ; 20 min sessions, 8 sessions, once/wk Drop outs: 8 (NR), based on total sample CG (n = 31) – Acu + Auricular acu-Tx: Acu as IG; after Acu, auricular needles were inserted (4 points in each ear) as follows: Shen menn pont, Lung point; Cervical column area, and Cephalea point; needles with diameter of 300 micro m and length of 18 mm were used and stimulated two at a time witha rotary movement dx/sx for 20s only at the moment of embedding; same as IG | Outcomes: Pain: MPQ; VAS Results: Baseline: Pain: IG = 40.7 (17.78), CG = 38.9 (15.31); IG = 57.9 (18.87), CG = 61 (20.73) Immediate post tx: Pain: IG = 13.32 (9.62), CG = 13.43 (10.96); IG = 15.64 (12.69), CG = 19.5 (19.31) Short term: IG = 14.2 (10.99), CG = 11.4 (12.16); IG = 15.3 (15.69), CG = 18.5 (17.96) Intermediate: IG = 15.64 (11.43), CG = 12.9 (13.87); IG = 18.96 (15.6), CG = 21 (19.88) Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR
Ga, H (2007)186 Country: Korea Quality score: 5/13 Initial of reviewer: SG | Trial Design: RCT Tx duration: not clear Fu duration (last assessment): 3 mos N screened: NR N randomized: 39 N completed tx: 39 N attended last fu: 39 Inclusion: Pts aged > 60 yrs complaining of chronic shoulder/NP or headache for more than 6 mo Exclusion: Pts who had had MTP injections or Acu within 6 mo preceding the study; neck/shoulder surgery within 1 yr; taking strong opioids (morphine); fibromyalgia; cervical radiculopathy, myelopathy; severe CVD or respiratory diseases; allergy to drugs/ injections, drug abuse; cognitive deficiency | Mean age (SD/range): IG = 79.2 (6.8) vs. CG = 75.9 (8.7) yrs % of male: IG = 5.5%, CG =9.5% Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: NR Duration of Pain, mean (SD/range): Chronic, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 18)– Acu: Used modified Simons et al technique on pts in prone position at TPs needled repeatedly without pause until all TPs were inactivated, needle diameter 0.3 mm and length 60 mm, needling depth was 30-35, all MTPs treated bilaterally; 3 txs at wks 0, 1, 2 Drop outs: 1 CG (n = 21) – Lidocaine: MTP injections, same method as IG using 5 ml syringes and 25 guage, 1.5 in long needles prefilled with 0.5% lidocaine, each MTP injected with 0.2 ml of lidocaine; same as IG Drop outs: 0 | Outcomes: Pain: VAS; FACES; PTS Results: Baseline: Pain: IG = 6.98 (1.32), CG = 6.43 (2.08); IG = 3.5 (0.71), CG = 3.43 (0.87); IG = 2.44 (0.7), CG = 2.19 (0.6) Immediate post tx: Pain: IG = 4.69 (2.05), CG = 3.9 (2.12); IG = 2.83 (0.99), CG = 2.62 (0.92); IG = 1.94 (0.87), CG = 1.76 (0.77) Short term: IG = 3.82 (2.47), CG = 3.46 (2.47); IG = 2.11 (1.13), CG = 2.25 (1.16); IG = 1.33 (0.69), CG = 1.71 (0.72) Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Other: Passive ROM Immediate post tx: Flexion: 68.9 (11.2) vs. 68.3 (14.8) Extension: 67.7 (14.1) vs. 65.0 (13.9) Short term: NR Intermediate: NR Long term: NR Harms: NR
Irnich D (2002)188 [crossover] Country: Germany Quality score: 8/13 Initial of reviewer: SG | Trial Design RCT Tx duration: single session (30 min.) Fu duration (last assessment): immediate post-tx N screened: 36 N randomized: 102 N completed tx: 101 N attended last fu: 101 Inclusion: Pts with chronic NP (> 2 mo) and myofascial or irritation syndrome Exclusion: radicular cervical syndrome, segmental instability, fractur or surgery of the cervical spine, contraindications to acu Tx, drug Tx, physical Tx or manual Tx any time in the last 4 wks | Mean age (SD/range): 51.9 yrs (total sample) % of male: 26.4% (total sample) Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: Myofascial syndrome Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Myofascial pain syndrome Duration of Pain, mean (SD/range): Chronic, 36.7 mo (total sample) Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: None | Groups IG1 (n = 34)– NL-Acu: affected channels were indicated by pain localization and direction of limited mobility; classical distant Acu points at the extremities were used; in addition, one-two ear points were chosen; single session, 30 min Drop outs: A = 1 IG2 (n = 34)– L-Acu (DN)[dry needling]: strong ME on tender spots called 'ah shi' points, needles inserted in local points and manipulated until local twitch obtained; Same as IG1 Drop outs: A = 1 CG (n = 34) – Sham-Laser acu: Using a handy laser pen emitting red light only, did not touch the skin(distance: 0.5-1 cm); Same as IG1 Drop outs: 0 | Outcomes: Pain: VAS motion-related(only crossover data reported) Results: Baseline: Pain: IG1 = 35 (22.64), IG2 = 33.4 (19.41), CG = 30.4 (18.62) Immediate post tx: Pain: IG1 = 19.1 (16.11), IG2 = 29.2 (21.9), CG = 28 (19.36) Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: No SAEs were observed
Li, DJ (2006)191 Country: China Quality score: 5/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 2 - 4 wks Fu duration (last assessment): 6 mos N screened: 150 N randomized: 150 N completed tx: 150 N attended last fu: 150 Inclusion: Spinal stenosis of neck; age < 69 yrs; Disease course < 2 yrs; Diagnosed by CT or MRI; Related signs is positive Exclusion: spinal trauma in 4 mo; Systemic infection and fever; Cervical tumor | Mean age (SD/range): 49 yrs total % of male: IG1 = 52%, IG2 = 56%, CG = 58% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Spinal stenosis Duration of Pain, mean (SD/range): Chronic (3 mo-2 yrs), NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = NR)– Spinal manipulation: NR; 1 tx/wk, 3 - 4 wks Drop outs: A = 0, B = 0, C = 0 IG2 (n = NR)– Warm acu: Acupuncture at Ashi points and then warm needle; 15 min/2 wks Drop outs: A = 0, B = 0, C = 0 CG (n = NR) – Combination: Spinal manipulation + Warm acu: NR; warm acu was performed twice after every one times of SM Drop outs: A = 0, B = 0, C = 0 | Outcomes (describe instrument used): Pain: VAS Results: Baseline: Pain: IG1 = 8.81 (1.82), IG2 = 8.84 (1.81), CG = 8.62 (1.39) Immediate post tx: Pain: --- Short term: IG1 = 4.43 (2.51), IG2 = 4.46 (3.11), CG = 2.36 (2.8) Intermediate: IG1 = 3.48 (2.5), IG2 = 2.04 (3.71), CG = 1.12 (2.78) Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: SM is effecitve for relieving muscle spasm & relaxing nerve root adhesion; warm acu more effective in eliminating the aseptic inflammation of the soft tissue & improving the blood suppy and relaxing the muscles
Lundenberg, T (1991)193 Country: Sweden Quality score: 1/13 Initial of reviewer: SG | Trial Design RCT Tx duration: one 40 min session Fu duration (last assessment): NR N screened: 58 N randomized: 58 N completed tx: 58 N attended last fu: NR Inclusion: 44 - 76 yrs; osteoarthritis of the cervical and/or thoracic spine (C1-T1) and with no previous experience of acu; pain for 6 mo or more Exclusion: sensory or motor deficit | Mean age (SD/range): NR % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP and/or TP Cause of Pain: Degenerative disease (osteo-arthritis) Duration of Pain, mean (SD/range): Chronic, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups CG (n = 14) – Sham-acu: Superficial needling; 40 min session Drop outs: 0 IG1 (n = 14)– Acu + ME: acu for 40 min on points Li 3 (bilateral), Du 14, Du 16, and Gb 20 (bilateral); manual rots of the needles after insertion for 10 sec/5 min.; As CG1 Drop outs: 0 IG2 (n = 15)– 2Hz elecro-acu: bipolar square wave pulses of 0.2 ms duration current adjusted to localized muscle contractions; As CG Drop outs: 0 IG3 (n = 15) – 80 Hz electro-acu: intensity was adjusted as that paraesthesias were evoked in the stimulated area; as CG1 Drop outs: 0 | Outcomes (describe instrument used): Pain: VAS sensory (10 cm); VAS affective (10 cm) [no data] Results: Immediate post tx: Sensory pain: 2.8 (1.3) vs. 1.8 (1.0) vs. 2.2 (1.7) vs. 2.4 (1.9) Affective pain score: 2.2 (1.2) vs. 1.8 (1.0) vs. 1.4 (1.5) vs. 1.5 (1.1) Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR
Lv, YX (2006)187 Country: China Quality score: 3/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 12 ds Fu duration (last assessment): immediate post-tx N screened: 80 N randomized: 70 N completed tx: 70 N attended last fu: 70 Inclusion: Cervico-genic headache Exclusion: NR | Mean age (SD/range): IG1 = 40.33 (8.16) vs. IG2 = 42.46 (6.72) yrs % of male: IG = 36.1%, CG = 41.2% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Cervico-genic headache Duration of Pain, mean (SD/range): Chronic (≥ 12 wks), NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: TDP | Groups IG1 (n = 36) – Turthe-probing needling: choice acupoint at Tian zhu, Feng chi, needle size 40 mm; 30 min/d x 6 d x 2 courses Drop outs: A = 0, B = 0 IG2 (n = 34) – Routine acu: choice acupoint at Tian zhu, Feng chi,shuai gu,Tou wei, Jia ji, Hou xi and Ashi, needle size 40 mm; Same as IG1 Drop outs: A = 0, B = 0 | Outcomes (describe instrument used): Pain: VAS Results: Baseline: Pain: NR Immediate post tx: Pain: p < 0.05 Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: Turtheprobing has fast onset of action and better than routine acu
Thomas, M (1991)195 Country: Sweden Quality score: 5/13 Initial of reviewer: SG | Trial Design RCT Tx duration: not clear Fu duration (last assessment): immediate post-tx N screened: NR N randomized: 44 N completed tx: NR N attended last fu: NR Inclusion: Pts with chronic cervical osteoarthritis, with pain for 6 mo or more. Pain more severe when joints are in movement than at rest Exclusion: NR | Mean age (SD/range): 42-77 yrs % of male: NR Racial composition: (assume all white) Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: Cervical ostearthritis (spine & neck) Cause of Pain: S, Osteoarthritis Duration of Pain, mean (SD/range): Chronic, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = 11) – Acu: Points were Li3, Du 14, Du16, Du20 and GB20 (bilateral). Needles were 2.5 cm long, Insertions made to depths 0.6-1.3 cm. Stimulation brought about by manual rots of needles which evoked tingling, deqi sensation; 40 min tx, repeated 10 sec/5 min by further rots, 3-5 d between trials Drop outs: NR for all CG1 (n = 11) – Sham-Acu: Needles inserted superficially and left without eliciting further sensation; 3-5 d between trials IG2 (n = 11) – Pts were administered 5mgm diazepam orally; As CG1 CG2 (n = 11) – Sham-Diazepam: pts given 5 mgm placebo-diazepam orally; as CG1 | Outcomes: Pain: VAS affective score (0-10); VAS sensory score (0-10) Results: Baseline: Pain: IG1 = 3.5 (1.2), CG1 = 3.1 (1.1), IG2 = 3.0 (0.8), CG2 = 2.7 (1); IG1 = 2.5 (0.8), CG1 = 2 (0.9), IG2 = 1.9 (0.7), CG2 = 1.9 (0.8) Immediate post tx: Pain: IG1 = 2.3 (1.5), CG1 = 2.4 (1.2), IG2 = 2.2 (1), CG2 = 2.2 (1.3); IG1 = 1.8 (1.2), CG1 = 1.6 (1.1), IG2 = 1.6 (0.7), CG2 = 1.7 (1) Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Results- mean : Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: Acu was significantly more effective than placebo-diazepam, but NSly more effective than diazepam or sham-acu
White, PF (2000)192 Country: US Quality score: 5/13 Initial of reviewer: SG | Trial Design-RCT-cross over Tx duration: 3 wks Fu duration (last assessment): immediate post-tx (data shown for 1^st^ phase before cross over) N screened: NR N randomized: 68 N completed tx: 68 N attended last fu: 68 Inclusion: pts with history of NP and cervical disk disease with a stable level of pain for a period of at least 3 mo before enrollment Exclusion: pain with a radicular components, a recent history of drug or alcohol abuse (< 1 yr), chronic use of opiod analgesics, past experience with electro-analgesic therapies, recent change in analgesic Med (< last 3 mo), or an inability to reliably complete the assessment tools use to measure short term outcomes. | Mean age (SD/range): 52 (23) yrs total % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NA Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Disc disease Duration of Pain, mean (SD/range): Chronic, 43 (19) mo Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = 68) – acu with ES at local points: 10 probed connected to 5 bipolar leads, stimulated for 30 min at alternating freq. of 15/30 Hz, intensity adjusted to produce gentle tapping sensation without muscle contraction, max. amp of 37 mA, pulse width of 0.7 ms; 30 min, 3 tx/wk for 3 wks Drop outs: 0 IG2 (n = 68) – acu with ES at remote points (LB) : Ten 32-guage acu-like needles to depth 2 – 4 cm into soft-tissue and/or paraspinous muscle in LB region; As IG1 Drop outs: 0 CG (n = 68) – acu needles only at neck: Same as IG2 but in cervical region according to dermatomal distribution of NP; As IG1 Drop outs: 0 | Outcomes: Pain: VAS (10 cm)[cross-over design] Disability: SF-36 Results: Baseline: Pain: 7.8 (2.5) Disability: NR Immediate post tx: Pain: NR Disability-mean change: IG1 = 7.9 (3.6), IG2 = 3.7 (1.9), CG = 3.4 (1.7) Decrease in pain (mean, SD%): 38% (17) vs. 9% (16) vs. 13% (18) Short term: NR Intermediate: NA Long term: NR | Outcomes: QoL/ well being: NR Quality of sleep (data not shown) Physical activity Use of analgesics Results- mean: Immediate post tx: Increased in physical activity, mean% (SD): 41% (21) vs. 11 % (17) vs. 16% (15) Decrease in average oral analgesic Med, mean% (SD): 37% (18) vs. 9% (13) 6% (15) Harms: only needle site AEs were mentioned Summary: IG1 produces greater short term improvement in pain control, physical activity, and quality of sleep in pts with chronic NP
Yang, T (2009)197 Country: China Quality score: /13 Initial of reviewer: SG | Trial Design RCT Tx duration: NR Fu duration (last assessment): 3 mos N screened: NR N randomized: 66 N completed tx: NR N attended last fu: NR Inclusion: Pts with chronic pain of cervical intervertebral disc Exclusion: NR | Mean age (SD/range): NR % of male: 50% total Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Cervical intervertebral disc Duration of Pain, mean (SD/range): Chronic, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 33)– Acupoint sticking: Tianding (LI 17), Futu (LI 18), Dazhui (GV 14), Tianzong (SI 11), etc.; NR Drop outs: NR CG (n = 33) – Acu: NR; NR Drop outs: NR | Outcomes (describe instrument used): Pain: NA Disability: NA Results: Baseline: NA Pain: NA Disability: NA Immediate post tx: Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Other: Effective rate Immediate post tx: IG = 93.5%, CG = 72.4% Short term: IG = 90.3%, CG = 65.5% Intermediate: NR Long term: NR Harms: NR Summary: IG has a satisfactory therapeutic effect on chronic pain of cervical intervertebral disc
Zhao, Z (2004)196 Country: China Quality score: 3/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 20 – 40 ds Fu duration (last assessment): immediate post-tx N screened: Don’t know N randomized: 106 N completed tx: 106 N attended last fu: 106 Inclusion: Diagnostic using Chinese Standard; X-ray show unstable of neck spinal and discs Exclusion: age < 18 or age > 60 yrs | Mean age (SD/range): IG = 47.34 (5.1), CG = 46.15 (3.5) yrs % of male: IG = 50.9%, CG = 47.2% Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: S Duration of Pain, mean (SD/range): Chronic, IG = 18.47 (2.5), CG = 16.51 (1.3) Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 53) – Shencongding moxibustion + acu: acu points: sishengchong, baihui 0.35mm diameter, 50mm long needle, puncture down to 20mm under skin, twist needles for 2-3 min, then moxibustion for 7 time, retention 60 min; 1 tx/d, 10 tx/course, 2 courses Drop outs: B = 0 CG (n = 53) – Acupuncture: other than moxibusion, the other procedures were the same IG; 2 tx/2 d, 10 tx/course, 2 courses Drop outs: B = 0 | Outcomes (describe instrument used): Pain: NA Disability: NA Results: Baseline: Pain: NA Disability: NA Immediate post tx: Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: Well being, n (%) Other: Results- mean: Baseline: Immediate post tx: IG = 51 (96.2%), CG = 44 (83%) Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: Shencongdin moxibusition has a definite therapeutic effect with a better clinical a pplication prospection for cervical headache
Zhu XM (2002)189 [crossover] Country: Australia Quality score: 7/13 Initial of reviewer: SG | Trial Design- RCT cross over Tx duration: 3 wks Fu duration: immediate post-tx N screened: NR N randomized: 29 N completed tx: 29 N attended last fu: 29 Inclusion: Pts with CNP, 31-71 yrs had neck complaints ≥ 6 mo, degenerative joint disease, osteoarthritis, cervical spondylitis, soft tissue injuries, cervical sprain or whiplash injury, pain felt in the neck and radiating to the occiput or shoulders limiting neck movement Exclusion: any neck condition < 6 mo, any viral (hepatitis or HIV), cancer, decreased or absent deep tendon reflexes, depression, fibromyalgia syndrome, pregnancy, previous cervical spine surgery, acu tx, hypertension, thyroid problem, or diabetes | Mean age (SD/range): IG = 50 (10.6) vs. CG = 48.9 (10.1) yrs % of male: IG = 64%, CG = 40% Racial composition: NR Work status: Unemployed: 30.95% Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: Neck injury, n = 17 Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic, IG = 79.8 (60) mo; CG = 59.7 (104.9) mo Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 14)– Acu: Chinese acu dry needling both on two local and 2 distal points; 9 sessions, 3 wks Drop outs: NR CG (n = 15) – Sham-Acu: sham acu points located 2-3 cm lateral to the real acu points; short needles used; weak electro-stimulation once/min was applied for two distal points; Same as IG Drop outs: NR | Outcomes: Pain: adapted MPQ; VAS; daily pain duration in 8 hrs (in hrs) Disability: NDI Results-Baseline: Pain: IG = 1.65 (0.6), CG = 1.67 (0.5); IG = 51.8 (24.9), CG = 40.3 (16.5); IG = 6 (3.8), CG = 8.3 (5.9) Disability: IG = 10.2 (4.7), CG = 8.2 (3.6) Immediate post tx: Pain: IG = 0.69 (0.3), CG = 1.05 (0.7); IG = 28.9 (15.5), CG = 21.1 (10.3); IG = 2.8 (3), CG = 5.6 (4.7) Disability: IG = 6 (5.5), CG = 5.7 (6.2) Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR

Table 2.4 Neck Pain - Acupuncture - Chronic - Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other outcomes; Harms
Abernathy, AP (2008)198 Abstract Country: US Quality score: 0/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 3 wks Fu duration (last assessment): immediately post and 6 mos after intervention N screened: 123 N randomized: 123 N completed tx: NR N attended last fu: NR Inclusion: pts ≥ 18 yrs old with uncomplicated NP for at least 3 mo, with motion-induced pain of at least 30 on 100 mm VAS Exclusion: NR | Mean age (SD/range): 46 47 yrs total % of male: NR(majority female) Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic (t least 3 mo) Severity of pain (Grading): VAS at least 30 at baseline Current tx/ co-intervention common in all groups: rescue Med for all pts if needed: diclofenac and tetrazepam | Groups IG (n = 113)– Acupuncture: points were chosen based on pain characteristics, and punctures were always bilateral; 5 tx sessions over 3 wks Drop outs: NR CG (n = 110) – TENS: NR; NR Drop outs: NR | Outcomes (describe instrument used): Pain: VAS (100 mm) Results: Baseline: Pain: IG = 68.7, CG = 42.3 Immediate post tx: Motion related NP, decrease from baseline: 42.1 vs. 14.0, p < 0.001 Short term: NR Intermediate: no numeric data reported. The outcome of pain was reported to be sustained from post tx Long term: NR | Outcomes (describe instrument used): QoL/ well being: SF-36 improvement from baseline: 6.3 vs. 0.7, p = 0.002 Short term: NR Intermediate: NR Long term: NR Harms: AEs were mild and affected both groups in the similar degree Summary: acu produced 3 times the beneficial effects of placebo. This study was single blinded.
Coan RM (1982)206 Country: US Quality score: 4/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 8 wks Fu duration (last assessment): 3 mos N screened: NR N randomized: 30 N completed tx: 30 N attended last fu: 30 Inclusion: Neck pain and/or radicular arm and hand pain ≥ 6 mo Exclusion: No history of diabetes, previous acu Tx, infection, or cancer | Mean age (SD/range): IG = 51.6 vs. CG = 47 yrs % of male: IG = 13.3%, CG = 40% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S; with radicular arm and hand pain Duration of Pain, mean (SD/range): Chronic, at least 6 mos Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: IG: Chiro: n = 1 CG: Chiro: n = 1 Traction: n = 3 Heat: n = 1 Diathermy: n =1 | Groups IG (n = 15)– Acu + Usual care: Performed according to the classical oriental meridian theory ; acu point selection varied from pt to pt; 3-4 tx/wk, 8 wks Drop outs: NR CG (n = 15) – Usual care: NR; NR Drop outs: NR | Outcomes (describe instrument used): Pain: VAS; Mean N of hrs with pain/d Results: Baseline: Pain: IG = 6, CG = 5.3; IG = 11.7, CG = 11.3 Immediate post tx: Pain: --- Short term: IG = 3.6 (2.21), CG = 5.4 (2.23); IG = 3.8, CG = 11.3 Intermediate: NR Long term: NA | Outcomes (describe instrument used): QoL/ well being: NR Mean pain pills/wk: Immediate post tx: NR Short term: (3 monhts fu) 7.5 vs. 8.7- change from baseline Intermediate: NR Long term: NR Harms: N of pts with worse pain than baseline: 0 vs. 4
David J (1998)207 Country: US Quality score: 4/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 6 wks Fu duration (last assessment): 6 mos N screened: NR N randomized: 70 N completed tx: 70 N attended last fu: 65 Inclusion: Pts aged 18-75 yrs with chronic NP (> 6 wks); types of NP were postural, whiplash injury, occupational NP, cervical spondylosis Exclusion: previous acu Tx or PT, neurological signs, primary piybromyalgia, inflammatory NP, rheumateoid arthritis, osteopathy, ankylosing spondylitis | Mean age (SD/range): IG = 48 (NR), CG = 44 (NR) yrs % of male: 28.6% total Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: Mechanical Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic (≥ 6 wks) Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 35)– Acu: sterile disposable 0.25 x 2.5 acumedic needles; TPs were needled; regional (GB21) and distal (L14) needling was also used; the needles were left in situ for 15 min and manually manipulated once at 7 min; 1 tx/wk, 6 tx, 6 wks Drop outs: A = 2, B = 3, D = 1 CG (n = 35) – PT: standard localized Mob techniques, most commonly Maitland rot, postero-anterior oscillatory movement and longitudinal traction; Same as IG Drop outs: A = 7, B = 2, D = 4 | Outcomes (describe instrument used): Pain: VAS; NPQ (no numerical data given) Results: Baseline: Pain: --- Immediate post tx: Pain: --- Short term: NR Intermediate: NR Long term: NA | Outcomes (describe instrument used): QoL/ well being: GHQ (no numerical data given) Results- mean: Baseline:--- Immediate post tx: --- Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: No differences were found in pain, disability, or well being in pts between Acu vs. PT groups at B and D; however, both Acu and PT were effective in within-group changes
Gallacchi G (1983)204,205 Country: Switzerland Quality score: 5/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 3-4 wks Fu duration (last assessment): immediate post-tx N screened: 121 N randomized: 113 N completed tx: 113 N attended last fu: 113 Inclusion: tendomyotical cervical and lumbar syndrome were under medical and/or physical tx for N of mos before volunteered for AP study Exclusion: NR (anyone not meeting inclusion criteria) | Mean age (SD/range): NR % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: Cervical spine Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic, NR Severity of pain (Grading): VAS but NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = 15)– acu with conv. needles at classical acu points, until propagated sensation-needle retention for 10 min, 2 tx/wk for 4 wks Drop outs: 0 CG1 (n = 14)– acu with placebe needles in classical acu points: at sites/techniques as in IG1; insertion at 5 mm under skin, 2 tx/wk for 4 wks Drop outs: 1 CG2 (n = 14)– acu with conv. needles at placebo points: as IG; 2 tx/wk for 3 wks Drop outs: 1 IG2-IG6 (n = 70)– laser AP at classical acu pts: 1) laser light, 2) no emission of rays, 3) mixed light, 4) red light, 5) infrared light; 60 sec/each AP point, 2 tx/wk for 4 wks Drop outs: 6 | Outcomes (describe instrument used): Pain: VAS averae (data shown in graphs, not extracted) Results: Baseline: Pain: NR Immediate post tx: Pain: NR Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: no significant differences between groups
Giles, LG (2003)25,26 Country: Australia Quality score: 5/13 Initial of reviewer: SG | Trial Design- RCT Tx duration: Max. of 9 wks Fu duration (last assessment): 12 mos N screened: 109 N randomized: 109 N completed tx: 109 N attended last fu: 62 Inclusion: pts at least 17 yrs old with uncomplicated mechanical spinal pain for minimum of 13 wks - for long-term fu (> 1 yr) Exclusion: pts with nerve root involvement, spinal anomalies (other than sacralization/lumbarization), pathology other than mild-moderate osteroarthrosis, spondylolisthesis of L5 or S1 > Grade 1, previous spinal surgery, and leg length inequality > 9 mm with postural scoliosis. | Mean age (SD/range): IG1 = 23.8 (4.8), IG2 = 25 (8.1), CG = 29.5 (2.07) yrs % of male: IG1 = 55.9%, IG2 = 51.4%, CG = 57.5% Racial composition: NR Work status: NR Other socio-demographics: Unemployed: 29 (25.7%) Co morbidities: NR Prior episode of pain if acute: NA Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: LBP, NP, thorax Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic (> 13 wks), NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = 34)– Acu: near and far techniques as chosen by clinician; 2 tx/wk, max. of 9 wks Drop outs: B = 12 IG2 (n = 35)– Spinal manipulation: 20 min-appointments. High-velocity, low-amplitude thrust SM to a joint (as judged to be safe and usual tx by the treating chiropractor for the spinal level of involvement to mobilize the spinal joints; same as IG1 Drop outs: B = 10 CG (n = 40) – Medication that have not been tried: Celecoxib/Celebrex (200 - 400 mg/d); Rofecoxib/Vioxx (12.5 - 25 mg/d); paracetamol/acetamino phen (500 mg tablest 2-6/dup to 4 g/d); NR Drop outs: B = 18 | Outcomes: Pain: VAS (1-100) Disability: Oswestry Back Results: Baseline: Pain: IG1 = 6 (2.2), IG2 = 6 (2.9), CG = 5 (3.7) Disability: IG1 = 30 (17.03), IG2 = 22 (22.96), CG = 32 (19.3) Immediate post tx: Pain: IG1 = 4 (4.4), IG2 = 5 (3.7), CG = 6 (4.4) Disability: IG1 = 26 (20.74), IG2 = 14 (24.4), CG = 32 (23.7) Long term: OBD: IG1 = 13 (22.9), IG2 = 16 (17.8), CG = 24 (25.2) VAS: IG1 = 3.9 (3.2), IG2 = 3.7 (4), CG = 3.9 (3.3) | Outcomes: QoL/ well being: SF-36 (higher values better) Results- mean: Baseline: IG1 = 46 (15.6), IG2 = 57 (22.9), CG = 37 (25.2) Immediate post tx: IG1 = 53 (22.2), IG2 = 70 (38.5), CG = 57 (33.3) Short term: NR Intermediate: NR Long term: IG1 = 55 (26.7), IG2 = 77 (23.7), CG = 66 (36.3) Harms: some pts had changed tx modality between the fu due to AE. no report of detail of AEs
Giles, LGF (1999)122 Country: Australia Quality score: 1/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 3-4 wks Fu duration (last assessment): immediate post-tx N screened: 875 N randomized: 40 N completed tx: 40 N attended last fu: 40 Inclusion: pts suffering from spinal pain for at least 13 wks; age of at least 18 yrs Exclusion: Nerve root involvements; spinal anomalities; pathology other than mild to moderate osteoarthrosis; previous spinal surgery and leg length inequality of > 9 mm with postural scoliosis | Mean age (SD/range): IG1 = 46.5 (9.6), IG2 = 42.5 (9.6), CG = 35 (14.1) yrs % of male: 35.7% total Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = 10)– Acu: using sterile HWATO Chinese disposable acu guide tube needles 50mm long with a gauge of 0.25 mm for 20 min tx, 3-4 wks Drop outs: NR IG2 (n = 20) – SM- high-velocity, low-amplitude SM was performed as judged to be safe; 6 tx, 3-4 wks Drop outs: NR CG (n = 10) – Medication: tenoxican (20mg/d) and ranitidine (50mg x 2/ d); 15-20 min/ appointment, 3-4 wks Drop outs: NR | Outcomes: Pain: VAS Disability: ODI Results: Baseline: Pain: IG1 = 40 (31.8), IG2 = 32 (14.8), CG = 28 (21.9) Disability: IG1 = 3.5 (5.5), IG2 = 5 (3.5), CG = 2.7 (4.8) Immediate post tx: Pain-mean change: IG1 = -6 (14.4), IG2 = -10 (10.4), CG = 0 (10.7) Disability-mean change: IG1 = -0.5 (4.8), IG2 = -2.3 (4.8), CG = -1 (1.3) Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR
Itoh K (2007)199 [crossover design] Country: Japan Quality score: 6/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: 3 wks Fu duration (last assessment): immediately post-tx N screened: NR N randomized: 36 N completed tx: 31 N attended last fu: 31 Inclusion: Pts with chronic NP (> 6 mo) age ≥ 45 yrs, no radiation of NP, well functioning cervical nerve, deep tendon reflexes, voluntary muscle action, sensory and function Exclusion: Major trauma or systemic disease, other ongoing tx except those receiving unified dosage for a mo or longer | Mean age (SD/range): IG1 = 62.3 (11) vs. IG2 = 62.3 (10.1) yrs % of male: 27.5% Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: Spondylosis n = 5; Discopath n = 3; Radiculopathy n=2 Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic, IG = 3.2 (3.1), CG = 2.9 (2.7) yrs Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: Povltice: IG: n = 7, CG: n = 6 Analgesic: IG :n = 2, CG: n = 3 Vit D: IG: n = 1, CG: n = 1 | Groups IG1 (n = 8) – Traditional acu: local points in cervical region: needles inserted into muscle to depth of 20mm-“sparrow pecking” technique-needle retention for 10 min –or until “deqi” sensation; 3 wks Drop outs: A = 2 IG2 (n = 8) – TP-Acu: applied to myofascial TPs located by palpation, local twitch elicited-similar technique as IG1.; 3 wks Drop outs: A = 2 CG1 (n = 10) – Non-TP-Acu: NR; NR CG2 (n = 10) – Sham-Acu: NR; NR | Outcomes: Pain: VAS Disability: NDI Results: Baseline: Pain: IG1 = 69.5 (18.6), IG2 = 67 (13.2), CG1 = 70.9 (14), CG2 = 64.1 (20.7) Disability: IG 1 = 12.6 (6), IG2 = 13 (6.3), CG1 = 15.1 (2.7), CG2 = 12 (3.6) Immediate post-tx: Pain: IG1 = 45.9 (17.5), IG2 = 18.6 (18.5), CG1 = 58.4 (16.9), CG2 = 54.6 (20) Disability: IG1 = 9.3 (5.2), IG2 = 3.9 (3.4), CG1 = 12.8 (2.1), CG2 = 11.3 (3.3) Short term: NR Intermediate: NR Long term: NA | Outcomes: QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NA Harms: NR
Nabeta T (2002)216 Country: Japan Quality score: 5/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 3 wks Fu duration (last assessment): 1 mo N screened: NR N randomized: 34 N completed tx: 27 N attended last fu: NR Inclusion: Pts with chronic pain/stiffness in neck and shoulder without arm symptoms Exclusion: NR | Mean age (SD/range): IG = 34.2 (10.8) vs. CG = 30.8 (12) yrs % of male: 29.4% total Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: Myofascial syndrome Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: Neck, shoulder Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 17)– Acu: Disposable stainless needles 0.2 x 40 mm inserted into the muscle to a depth of 20 mm and the 'sparrow pecking' technique was applied; when dull pain or acu sensation was felt, the manipulation was stransverse oscillatory rotped and the needle was retained for 5 more min; 3 tx, 3 wks Drop outs: 2 (A - B) CG (n = 17) – Sham-Acu: similar needles used but tips had been cut off and smoothed to prevent penetration of skin; acupuncturist pretended to insert the needle and use the sparrow pecking technique, then removed needles; needle extraction simulated after 5 min by touching the pt, noisily dropping needles into a metal cases; as IG Drop outs: 5 (A - B) | Outcomes: Pain: VAS; PPT Results: Baseline: Pain: IG = 60.5 (15), CG = 48.8 (28); IG = 1.7 (0.7), CG = 1.6 (0.9) Immediate post tx: Pain: IG = 43.3 (19.7), CG = 46.8 (25.4); IG = 2.6 (1.9), CG = 1.3 (0.5) Short term: NR Intermediate: NR Long term: NA | Outcomes (describe instrument used): QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: authors indicate that AEs were not the cause of drop out
Petrie J (1986)202 Country: UK Quality score: 5/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 4 wks Fu duration (last assessment): 3 mos N screened: 27 N randomized: 25 N completed tx: 24 N attended last fu: 24 Inclusion: chronic NP (at least 6 mo) Exclusion: peripheral synovitis or malignancy | Mean age (SD/range): IG = 52.9 (9.8) vs. CG = 48.1 (12.8) yrs % of male: IG = 31 %, CG = 42% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic, IG = 18 (11.2) mo; CG = 26.5 (26.4) mo Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 13)– Acu: Five 28 g standard acu needles inserted at points GB20 and GB21 bilaterally and Du14 in the mid-line. The sensation of “The Chi” was obtained by ME on insertion and at 5 min intervals for 20 min; 20 min, twice/wk for 4 wks Drop outs: B = 0, C = 0 CG (n = 12) – Sham transcutaneous nerve stimulation (TNS): sweep function signal generator placed on transverse oscillatory rot of an oscilloscope. When the apparatus was switched on, the controls of the signal generator were set to display a pulsed high-frequency pattern on the oscilloscope in front of the pt; Same as IG Drop outs: B = 1 (unrelated surgery), C = 0 | Outcomes: Pain: MPQ; Daily pain intensity score Results-Baseline: MPQ: IG = 20.38 (10.93), CG = 14.42 (6.13); Pain intensity: IG = 47.08 (15.88), CG = 31.67 (16.55) Immediate post tx: MPQ: IG = 15.54 (13.68), CG = 14.58 (9.68) Pain intensity: IG = 36.59 (22.95), CG = 32.88 (18.55) Short term: MPQ:IG = 13.85 (11.86), CG = 11.55 (8.66) Pain intensity: IG = 31.77 (24.1), CG = 24.72 (20.6) Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Daily pill count, mean (SD) Immediate post tx: 2.71 (2.56) vs. 1.24 (1.05) Short term: 2.41 (2.66) vs. 0.87 (0.55) Intermediate: NR Long term: NR Harms: one ptient in placebo group experiences negative effects (WDAE) Note: n=2 in IG and n=1 in CG had complete recovery of pain at last fu
Petrie JP (1983)203 Country: New Zealand Quality score: 6/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 4 wks Fu duration (last assessment): immediate post-tx N screened: NR N randomized: 13 N completed tx: 13 N attended last fu: 13 Inclusion: Chronic cervical pain (> 2 yrs) defined as pain in the neck radiating to the occiput and /or shoulders with some limitations in movement Exclusion: active synovitis, neoplasia, steroid or local anesthesia injections to the neck in the previous mo | Mean age (SD/range): 65 yrs total % of male: IG = 14.3%, CG = 50% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: (n) rheumatoid arthritis: 6; osteoarthritis: 6; ankylosing spondylitis: 2 Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic (≥ 2 yrs), NR Severity of pain (Grading): majority with moderate pain Current tx/ co-intervention common in all groups: anti-inflammatory and analgesics, PT, hot packs, pool therapy | Groups IG (n = 7) – Acu: Five standard points were chosen: Du14, GB20, GB 21 (bilateral points), traditional needles 28 g were used to achieve sensation of The Chi described as numbness, soreness, heaviness at the point of insertion; the needles manipulated for 10 min after insertion, no electro stimulation applied; 20 min session, twice/wk, 4 wks Drop outs: NR CG (n = 6) – TENS placebo: sham stimulation; lead electrode applied to each side of the neck 5 cm lateral to C7; although the red light was switched on and the stimulator controls adjusted to the full view of the pt, no electrical current was passing to electrodes; Same as IG Drop outs: NR | Outcomes (describe instrument used): Pain: pain relief: 5-point scale (no relevant outcome reported) Results: Immediate post tx: Very good or good pain relief: 6 pts in IG vs. 0 in CG Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: Acu superior to TENS-placebo after 4 wks of Tx.
Salter GC (2006)200 Country: US Quality score: 6/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 3 mos Fu duration (last assessment): immediate post-tx N screened: 227 N randomized: 24 N completed tx: 24 N attended last fu: 24 Inclusion: Pts with chronic NP aged 18 yrs or older who had consulted the NP practice in the previous 12 mo Exclusion: Cancer, rheumatoid arthritis, or ankylosing spondylisis, pain below the elbow, neck surgery, hemophilia, acu, awaiting legal action or not consenting | Mean age (SD/range): IG = 50.8 (17.1) vs. CG = 45.5 (16.4) yrs % of male: IG = 30%, CG = 21% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic, IG = 5.7 (6.4); CG = 5.5 (5.5) yrs Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 10) – Acu + GP: Acu: 5-24 needles/tx; 13-50 mm length with guage between 0.18-0.36 mm and insertion depth of 0.2-2.5 cm common points were GB-21, Ah Shi, GB-20, Huatuojaji at C-6, S-13, and Huatuojaji at C-7; other techniques such as massage, relaxation, diet, EX, and rest; GP: Med, massage, recommended EX; 3 mo Drop outs: A = 1, B = 1 CG (n = 14) – GP: Med, massage, recommended EX; 3 mo Drop outs: A = 2, B = 2 | Outcomes (describe instrument used): Pain: NPQ- lower better Results: Baseline: Pain: IG = 34.31 (11.7), CG = 38.4 (18.6) Immediate post tx: NR Short term: NR IG = 22.73 (18.64), CG = 25.72 (16.29) Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: SF-36: no numerical values reported. Use of Med at bseline: 40% vs. 42.9% Immediate post tx: NR Short term: 3 monhts post tx: 11.1% vs. 41.7% Intermediate: NR Long term: NR Harms: IG – n = 6: aggravation of symptoms; n = 6: dizziness; n = 4: tiredness; CG – No SAE occured
Sator-Katzenschlag SM (2003)215 Country: Austria Quality score: 4/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 6 wks Fu duration (last assessment): 3 mos N screened: NR N randomized: 21 N completed tx: NR N attended last fu: NR Inclusion: Chronic cervical pain (≥ 6 mo), normal neurologic function, of cervical nerves with no pain radiation, neural or spinal structure pathology, VAS ≥ 5 Exclusion: allergy to lornoxicam or tramadol, history of drug abuse, pregnancy, concomitant use of TENS or pacemaker, history of acu Tx | Mean age (SD/range): IG = 52 (12) vs. CG = 52 (9) yrs % of male: 28.5% total Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: muscular origin, spondylarthrosis, localized protrusion of a disc Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic, 3.3 (1.2) (total sample) Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = 11)– Manual conventional Acu: acu points: cervical spine (37), shen men (55), and cushion (29, 19) by determining the position of the least skin resistance using electric conductance meters; no ES was administered; all needles removed after 48 h of insertion; once/wk for 6 wks Drop outs: 1 (A-B) IG2 (n = 10) – Electro-Acu- auricular: same as IG + the needles were connected to P-STIM which is positioned behind the ear like a hearing aid; needles were continuously stimulated with 2 mA constant current at freq. of 1 Hz for 48 h; all needles removed after 48 h of insertion; Same as IG Drop outs: 1 (A-B) | Outcomes (describe instrument used): Pain: VAS (numerical data NR) Results: Baseline: Pain: NR Immediate post tx: Pain: NR Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: No numerical data reported Consumption of rescue Med Immediate post tx: NR Short term: Tablets mean (SD) 107 (5.0) vs. 47 (8.0) Intermediate: NR Long term: NR Harms: No AE was observed Summary: Statistically significantly larger reduction in VAS pain scores and improved well-being in the E-Acu-Acu arm vs. Manual-Acu
Seidel (2002)201 Country: Germany Quality score: 10/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 4 wks Fu duration (last assessment): 3 mos N screened: 48 N randomized: 51 N completed tx: 48 N attended last fu: 48 Inclusion: at least 6 mo of pain as defined by Schoeps & Senn for cervical syndrome; age 20 – 72 yrs; consent; no AP tx for past 6 mo Exclusion: acute blockages within past 3 wks before tx; ongoing process regarding retirement money decision making; neuro, vascular dysfunction, fibromyalgia, epilepsy, acute fever-related diseases, alcohol, Med and drug abuse; other Med | Mean age (SD/range): CG1 = 47, CG2 = 47, CG3 = 48, IG = 56 yrs % of male: 9.8% total Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: No Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: Cervical spine Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic (18 – 480 mo), NR Severity of pain (Grading): VAS pain intensity Current tx/ co-intervention common in all groups: None | Groups CG1 (n = 13)– Sham (low level laser therapy, LLLT) on AP points 0 mW: without skin contact – continuing infrared laser, wave length 830 nm; 8 sessions, 2 sessions/wk for 4 wks Drop outs: 1 CG2 (n = 12) – LLLT 7 mW: as CG1; NR Drop outs: 0 CG3 (n = 13) – LLLT 30 mW: as CG1; 1 min radiation/ AP point, max. 15 points Drop outs: 1 IG (n = 13) – Acu: Conventional AP but individualized to location of pain; 15 min/session, max. 15 needles/session, 0.2 – 15 mm needle depth until De-Qi Drop outs: 1 | Outcomes: Pain: VAS average intensity; PPT (data not shown) Disability: NR Results- Immediate post tx: Pain: CG1 = 25.2, CG2 = 16.8, CG3 = 24.9, IG = 7.0 Short term: 4 wks after the last intervention, reduction in pain IG 82.2% vs. CG2 55.4% vs. CG3 29.1 % vs. CG1 26.1% Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Cervical movement – axial rot Immediate post tx: CG1 = 137 (15.14), CG2 = 133.3 (20.79), CG3 = 142.1 (13.34), IG = 135.3 (16.95) Short term: NR CG1 = 122.4 (41.1),CG2 = 137.8 (14.55), CG3 = 128.9 (22.35), IG = 129.2 (15.14) VAS: CG1 = 19.6, CG2 = 17.7, CG3 = 25.2, IG = 9.4 Intermediate: NR Long term: NR Harms: NR Summary: AP is therapeutic option in tx of common NP
Vas, J (2006)208 Country: Spain Quality score: 7/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 3 wks Fu duration (last assessment): 6 mos N screened: 149 N randomized: 123 N completed tx: 123 N attended last fu: 85 Inclusion: 17 yrs and over with uncomplicated NP over 3 mo duration, symptomatic at examination, motion-related NP intensity 30 and over measured on 100mm VAS, no tx during past wk Exclusion: previous acu tx; NP intensity < 30 on 100 mm VAS; dx of neuropathologic, infectious, inflammatory, neoplasic, endocrine, metabolic or visceral NP; fracture or traumatism; px pinal surgery; N-S fever; sever psychiatric illness; severe disorder of overall health state; pregnancy | Mean age (SD/range): IG = 46 (13.7) vs. CG = 47.4 (12.8) yrs % of male: IG = 24.6%, CG = 11.3% Racial composition: NR Work status: NR Other socio-demographics: 28.4% sedentary Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S, 55.25% arthritis, 30.9% rectification % NS: 13.85 % S: 86.15 Duration of Pain, mean (SD/range): Chronic (> 3 mo), IG = 47.4 (60.3) mo; CG = 43 (40.8) mo Severity of pain (Grading): ≥ 3 VAS Current tx/ co-intervention common in all groups: rescue Med - 50mg diclophenac; 50mg tetrazepam | Groups IG (n = 61) – Acu: bilateral points with 25mm x 0.25 mm or 40mm x 0.25 mm manually stimulated every 10 min; -“deqi” sensation; needle retention 30 min; Vaccaria seeds taped in ear auricle after sterlizing skin after removing needles; pts instructed to apply pressure to each ear point 10 repeats 3 times/d; 5 sessions over 3 wks Drop outs: B = 3, C = 13 CG (n = 62) – Placebo (TENS):; electrodes at GB 21 bilateral point with pt in prone position; nerve stimulation unit in front of Pt for 30 min with visible and audible flasing diode; Pt checked every 10 min and TENS-placebo potentiometer adjusted Drop outs: B = 5, C = 17 | Outcomes: Pain: VAS (0-100 mm); Northwick park NPQ (Spanish) Disability: ACM; PCM Results: Immediate post tx: Pain-mean change: IG = 44.1, CG = 12.3; IG = 30.2, CG = 12.7 Disability-mean change: IG = 57.2, CG = 33.6; IG = 17.3, CG = 8.9 Short term: Pain-mean change: IG = 41.1, CG = 26.8 Intermediate: NR Long term: NR | Outcomes: QoL/ well being: SF-36: physical score Results- mean: Baseline: IG = 36.7 (9.7), CG = 37.6 (7.9) Immediate post-tx-mean change: IG = 6.3, CG = 0.7; IG = 5.8, CG = 6.3 Short term: NR Intermediate-mean change: IG = 9.3, CG = 5.3 Long term: NR Harms: mild AEs similar rated in IG and CG (Acu: 4 AEs swelling of hands, bruising, pain and ulcer of the ear vs. placebo 2 Aes cepalea, and aggrevation of symptoms)
White P (2004)213,214 Country: UK Quality score: 9/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 4 wks Fu duration (last assessment): 12 mos N screened: 202 N randomized: 135 N completed tx: 135 N attended last fu: 106 Inclusion: Pts aged 18-80 yrs with chronic mechanical NP (> 2 mo) and a pain score > 30 mm on VAS (0-100 mm) for 5 of 7 pre-Tx ds Exclusion: Pregnancy, history of fracture, surgery of the neck, cervical congenital abnormality, uncontrolled LBP, contraindication to acetaminophen, systemic illness, recent or current manual neck Tx or steroid use | Mean age (SD/range): IG = 53.9 (15.71) vs. CG = 52.8 (15.6) yrs % of male: IG = 34.28%, CG = 36.9% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: Mechanical conditions Prior CAM intervention: NR Prior surgery related to current complaint: None | Region of pain: NP Cause of Pain: N-S, Majority had spoldylosis Duration of Pain, mean (SD/range): Chronic, IG = 4.81 (7.03) yrs; CG = 7.71 (11.4) yrs Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: Acetaminophen | Groups IG (n = 70)– Acu: Single-use sterile needles without guide tubes with sizes 13, 25, or 40 mm x 0.25 mm point selection based on individualized western acu techniques; S points determined by pain distribution, palpation of the neck and thorax to find ah-shi points/local tender points. At least one distal point was used; 6 points on avg/side if pain was bilateral and deqi was obtained; 20 min, twice/wk for 4 wks Drop outs: D = 16 CG (n = 65) – TENS-Placebo: The Noma FM-4 el-acu stimulator was used, the cables were severed at the output plug and no current was delivered to the pt; examination and point selection were the same as in IG; Same as IG Drop outs: D = 12 | Outcomes: Pain: VAS Disability: NDI Results: Immediate post tx: Pain: IG = 24.34 (21.63), CG = 34.38 (22.33) Disability: NR Short term: NDI: IG = 11.78 (6.59), CG = 12.34 (7.35) VAS: IG = 20.39 (20.26), CG = 30.69 (22) Intermediate: NDI: IG = 8.89 (6.57), CG = 10.72 (9.11) VAS: IG = 20.91 (25.7), CG = 24.36 (26.7) | Outcomes: QoL/ well being: SF-36 (physical score)- no change at 8 wks post tx (data not shown) Results- mean: Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: increase in symptoms after tx (n = 1), faintness (n = 3), mild headache (n = 2), dizziness (n = 2), tiredness (n = 1), thumb tingling (n = 1), cold feeling (n = 1), nausea (n = 1), discomfort (n = 1), hand swelling (n = 1), bruise at LI 4 (n = 1), euphoria and enhanced vision (n = 1)
Witt CM (2006)209,210-212 Country: Germany Quality score: 7/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: 3 mos Fu duration (last assessment): immediate post-tx N screened: NR N randomized: 3451 N completed tx: 3162 N attended last fu: 3162 Inclusion: chronic NP (> 6 mo), age ≥ 18 yrs Exclusion: prolapse of at least one intervertebral discs with concurrent neurological symptoms, prior vertebral surgery, spondylopathy, NP caused by inflammatory, cancer or autoimmune disease, congenital deformation of spine except scoliosis lordosis, compression fracture caused by osteoporosis; spinal stenosis | Mean age (SD/range): IG = 49.8 (12.8) vs. CG = 51.4 (13) yrs % of male: IG = 31 %; CG = 32% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic, IG = 6 (6.9); CG = 6.1 (7.3) yrs Severity of pain (Grading): Current tx/ co-intervention common in all groups: Usual care | Groups IG (n = 1753) – Acu: only standard acu with disposable needles permitted; conventional Tx as needed; 15 sessions over 3 mo Drop outs: B = 29 CG (n = 1698) – Control: conventional Tx as needed; NA Drop outs: B = 22 | Outcomes: Pain: NPDS Disability: SF-36: physical functioning; physical component Results: Baseline: Pain: IG = 55 (15.8), CG = 53.9 (16) Disability: IG = 63.6 (21.6), CG = 63.9 (22.8); IG = 37.6 (8.4), CG = 38.1 (9.1) Immediate post tx: Pain: IG = 38.3 (16.1), CG = 50.5 (15.7) Disability: NR, only % increase reported Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: SF- 36 (role physical)- % reduction, mean (95% CI) Immediate post tx: 24.5 (22.6, 26.5) vs. 5.1 (3.3, 7.0); CG vs. IG 9.4 (16.7, 22. 1), p < 0.001 Short term: NR 23.2 (21.1, 25.2) vs. 20.6 (18.4, 22.8), CG vs. IG 2.5 (-0.5, 5.6), p = 0.097 Intermediate: NR Long term: NR Harms: any AE, 1216 (n=1002) 57% minor local bleeding or hematoma, 10% pain, e.g., needling ain, 4% vegetative symptoms and 29% other). No ife-threatening side effects were reported.

Table 2.5 Neck Pain - Acupuncture - Mixed - Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other outcomes; Harms
Bin, X (2007)217 Country: China Quality score: 5/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 10ds Fu duration (last assessment): NR N screened: NR N randomized: 57 N completed tx: 54 N attended last fu: NR Inclusion: age 18-70 yrs; diagnosed with cervical spondylopathy; abnormal findings in X -ray exam; excluding ocular or aural vertigo, cases caused by poor blood supply in basilare arterial due to pressure on the verebroartery section I and III; also cases due to neurosis and intracranial tumor) Exclusion: conditions caused by such diseases as Meniere's cerebral arteri sclerosis, postural vetigo, drug intoxication of inner ear, neurosis, and sublavian steal syndrome | Mean age (SD/range): 35-68 yrs % of male: 73% total Racial composition: assume Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: Cause of Pain: Cervical spondylopathy of the vertebroarterial type Duration of Pain, mean (SD/range): Mixed (1 wk-10 yrs), NR Severity of pain (Grading): excluded mild; total: majority moderate (8 severe, and 49 moderate) Current tx/ co-intervention common in all groups: NR | Groups IG (n = 29) – Electro-acu:on acu points: GB 20; GV 20; GB 8; oblique insertion (75° angle) -gentle lifting thrusting and rotating manipulation was performed to induce the arrival of qi before and electric stimulator was connected to the needles; The points selected wer divided into two groups wich were used alternately; 20 min/session, once daily with a 10 d course Drop outs: 1 CG (n = 28) – simple acu: same acupoints and manipulation methods as IG; Same as IG Drop outs: 2 | Outcomes (describe instrument used): Pain: NA Disability: NA Results: Baseline: NA Pain: Disability: Immediate post tx: Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: Life and work- mean (SD) Post tx: 3.38 (2.43) vs. 2.74 (2.39) Cure rates Immediate post tx: pts completely cured (n): 10 vs. 6; cured & markedly effective rate: 82.21 vs. 53.84; Effective rate: 92.86 vs. 84.62 Change of physica signs: data not shown Quality of life: Short term: NR Intermediate: NR Long term: NR Harms: NR
Chu J (1997)221 Country: US Quality score: 1/13 Initial of reviewer: SG | Trial Design RCT Tx duration: NR Fu duration (last assessment): immediate post-tx N screened: 296 N randomized: 164 N completed tx: NR N attended last fu: NR Inclusion: Neck and arm pain, MPS due to cervical nerve root irritation Exclusion: Pts with peripheral neuropathy | Mean age (SD/range): NR % of male: IG = 41%, CG = 28.5% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: Cervical nerve root irritation Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: Neck, shoulder Cause of Pain: S, NR Duration of Pain, mean (SD/range): Mixed, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 122) – Acu (dry needling) – tender points: Done bilaterally on levator scapulae C3, trapezus C4, anteroir deltoid C5, romboid major C5, infraspinatus C5, posterior deltoid C6, biceps brachii-short head C7, brachialis C6, teres major C6, triceps C7, extensor communis C7, and cervical muscles at C3-C7 level; NR Drop outs: NR CG (n = 42) – Acu (dry needling) – random points: Same as IG; NR Drop outs: NR | Outcomes (describe instrument used): Pain: ≥ 50% pain relief, n (%)] Results: Baseline: Pain: --- Immediate post tx: Pain: IG = 38 (31%), CG = 7 (16.6%) Average pain relief: 51.8% (21.9) vs. 39.0% (18.7%) Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR
Huang, YF (2008)226 Country: China Quality score: 4/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 20 ds Fu duration (last assessment): immediately post-tx N screened: NR N randomized: 107 N completed tx: 107 N attended last fu: 107 Inclusion: numbness, NP, and radiating pain towards upper limb; brachial plexus traction test (+), spurling's test (+); deformity of cervical vertebrae in CT; cervical vertebrae affected determined by clinical evaluation same as those indicated in CT Exclusion: other cervical disc or joint disease or musculoskeletal disease affect upper limb, such as spinal tuberculosis, tumor, scapulohumeral periarthritis, etc. | Mean age (SD/range): IG1 = 43 (13), IG2 = 41.5 (10), CG = 41.7 (11.7) yrs % of male: IG1 = 64.9%, IG2 = 61.1%, CG = 70.6% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Cervical spondylosis of nerve root type Duration of Pain, mean (SD/range): Mixed: (up to 12 wks)/(>12 wks): IG1 = 4 (3.5), IG2 = 4 (3.5); Chronic (> 12 wks): CG = 4.6 (3.6) Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = 37)– Acu at Jiquan (HT1) with lifting thrusting manipulation: affected arm needled 25-40mm deep at 5cm below HT1 in abduction position and shoulder flx in 90°, needle stimulated by lifting-thrusting after “deqi” sensation reached; 1 session/2 d over 20 d Drop outs: A = 0, B = 0 IG2 (n = 36)– Acu at Jiquan (HT1) with twirling manipulation: same as IG1, stimulate needle site by twirling at freq. of 2 Hz till “deqi” sensation; as IG1 Drop outs: A = 0, B = 0 CG (n = 34) – Routine needling: needle 25-40 mm at LI 11, HT1, LI 4, PC6, PC3, manually stimulated till “deqi” sensation, retention time 30 min; as IG1 Drop outs: A = 0, B = 0 | Outcomes (describe instrument used): Pain: NA Disability: NA Results: Baseline: NA Pain: Disability: Immediate post tx: NA Pain: Disability: Short term: NR Intermediate: NR Long term: NA | Outcomes (describe instrument used): QoL/ well being: Cure rate; effective; ineffective; total efficacy (%) Immediate post tx: IG1 = 59.5, IG2 = 25, CG = 32.4; IG1 = IG1 = 32.4, IG2 = 33.3, CG = 44.1; IG1 = 8.1, IG2 = 41.7, CG = 23.5; IG1 = 91.9, IG2 = 58.3, CG = 76.5 Short term: NR Intermediate: NR Long term: NR Harms: NR
Ilbuldu E (2004)223 Country: Turkey Quality score: 5/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 4 wks Fu duration (last assessment): 6 mos N screened: NR N randomized: 60 N completed tx: 60 N attended last fu: 60 Inclusion: Women aged 18-50 yrs with MTP in the upper trapezius muscle Exclusion: Tumor, infectious diseases, osteoarthritis (stage 3-4), pregnancy, scoliosis, COLD | Mean age (SD/range): IG1 = 35.3 (9.18), IG2 = 33.9 (10.36), CG = 32.35 (6.88) yrs % of male: 0 (all female) Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Myofascial pain Duration of Pain, mean (SD/range): Mixed, IG = 38.48 (32) mo; IG2 = 32.95 (28.61) mo; CG = 36.95 (33.65) mo Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: paracetamol for pain | Groups IG1 (n = 20)– Acu dry needling: 0.25 x 25 size acu needles; once/wk for 4 wks Drop outs: NR IG2 (n = 20)– Laser therapy: He-Ne laser at 632.8 nm wavelength applied to the three TP in the upper trapezius muscles on both sides; 3 sessions/wk, 12 sessions over 4 wks Drop outs: NR CG (n = 20) – Laser-placebo: everything the same as in Laser group but no beam was applied; same as IG2 Drop outs: NR | Outcomes: Pain: NHP; VAS (at rest) Results: Baseline: Pain: IG1 = 70 IG2 = 59.54 (30.71), (19.47), CG = 60.42 (31.39); IG1 = 5.1 (1.97), IG2 = 5.5 (1.96), CG = 5.7 (1.81) Immediate post tx: Pain: NR Short term: IG1 = 33.9 (28.37), IG2 = 13.5 (14.07), CG = 32.2 (28.4); IG1 = 3.71 (2.33), IG2 = 2.05 (1.43), CG = 3.65 (2.03) Intermediate: IG1 = 32.66 (35.15), IG2 = 19.02 (23.02), CG = 27.89 (23.65); IG1 = 2.59 (2.18), IG2 = 2.12 (1.9), CG = 2.89 (2.63) | QoL/ well being: Nottingham Health profile inventory: laser grp was sig better than IG1 and CG at post tx but not at 6 mos Cervical ROM: sig increase in flexio at post tx in dry needling & laser grps, range of ext sig increased in laser grp vs. dry needling & placebo Analgesic use: Immediate post tx: analgesic use: 3.62 (4.41) vs. 0.85 (1.53) vs. 2.05 (3.38) Short term: NR Intermediate: NR Analgesic use: 2.53 (2.74) vs. 1.41 (3.43) vs. 2.5 (3.49) Long term: NR Harms: NR
Jia, CS (2007)225 Country: China Quality score: 5/13 Initial of reviewer: SG | Trial Design RCT Tx duration: one tx Fu duration (last assessment): immediate post-tx N screened: NR N randomized: 98 N completed tx: 98 N attended last fu: 98 Inclusion: diagnosed as cervical spondylosis according to “The diagnostic criteria for cervical spondylosis”; NP; informed consent obtained Exclusion: other spinal disease; pregnant and postnatal woman; cardio-cerebrovascular disease, hematransverse oscillatory rotoietic disease, psychosis; not complete tx sessions | Mean age (SD/range): NR % of male: 51% total Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Disc/joint disease Duration of Pain, mean (SD/range): Mixed (sub-acute/chronic) Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: head movements (rot, flx, ext, etc.) | Groups IG1 (n = 49) – Otransverse oscillatory rotoint- penetrative needling: needles inserted at unilateral and bilateral (AH 13) otransverse oscillatory rotoints and subsequently crossed one otransverse oscillatory rotoint area to another between epidermis and cartilage of muscle, stimulate with twirling 5-7 times, retention time 30 min., twirling 2-3 times during retention; one 30 min. tx Drop outs: A = 0 IG2 (n = 49) – Otransverse oscillatory rotoint- straight needling: needles directly inserted at selected otransverse oscillatory rotoints, needle retention time and twirling times same as IG1; Same as IG1 Drop outs: A = 0 | Outcomes: Pain: SF-MPQ (15 descriptors) Disability: NA Results: Baseline: Pain: IG1 = 28 (7.4), IG2 = 27.9 (7.3) Disability: NA Immediate post tx: Pain: IG1 = 12.6 (4.9), IG2 = 21.4 (6.4) Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR
Li, Xiang-hui (2004)219 Country: China Quality score: 4/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 40 ds Fu duration (last assessment): 12 mos N screened: 780 N randomized: 780 N completed tx: 780 N attended last fu: 780 Inclusion: Pts diagnosed as cervical spondylosis using Chinese Medical Diagnostic and Effectivenes Standard Exclusion: NR | Mean age (SD/range): IG = 49.1, CG1 = 50.2, CG2 = 48.1 yrs % of male: IG1 = 47.3%, CG1 = 45.8%, CG2 = 46.2% Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Spondylosis Duration of Pain, mean (SD/range): Mixed (1 mo-20 yrs, acute, sub-acute, chronic) Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 260) – Acu centro-square needling Danzhui: Dazui point, supplement acupoints: jianyu, jianzhen, jianqian, quchi, hegu, fengchi, huantiao, yanglingquan, neiguan and zusanli Diameter 0.30-0.35mm, 25-125mm long needle; 1 tx/d, 20 tx/course, 2 courses Drop outs: B = 0, E = 0 CG1 (n = 260) – Acu needling cervical Jiaji point: Jiaji point, Diameter 0.30-0.40mm; Same as IG1 Drop outs: B = 0, E = 0 CG2 (n = 260) – Traction-massage: traction 2-10kg, retention 30min, 10-15 neck massage; Same as IG1 Drop outs: B = 0, E = 0 | Outcomes (describe instrument used): Pain: NA Disability: NA Results: Baseline: Pain: NA Disability: NA Immediate post tx: Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: Based on Chinese Medical Diagnostic n (%) Results- mean: Immediate post tx: IG = 254 (97.7), CG1 = 247 (95), CG2 = 224 (86.2) Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: The therapeutic effect in IG1 was stable and better than that in the CGs. IG has the best therapeutic effect for cervical spondylosis and therapeutic effect of CG1 is better than that in CG2
Lin, M (2004)220 Country: China Quality score: 3/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 3 mos Fu duration (last assessment): 6 mos N screened: 100 N randomized: 100 N completed tx: NR N attended last fu: NR Inclusion: Cervical spondylopathy of nerve root type, aged 25-76 yrs Exclusion: NR | Mean age (SD/range): 46 (8.5) yrs total % of male: 65% total Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: | Region of pain: NP & Vertebrae Cause of Pain: Cervical spondylopathy of nerve root type Duration of Pain, mean (SD/range): Mixed(Acute-Chronic: 15 d – 32 yrs), NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | IG (n = 50) – Acu (Needle Scalpel/ Massage Tx): no. 3 or no. 4 small needle scalpel, cut lines parallel to nerves, blood vessels, muscle fiber, inserted vertically, small hole made with Chuanketie after needle withdrawn, pressure applied until bleeding stransverse oscillatory rotped, every 7 d Massage therapy: digital acupoint pressure, pokingchannels, on-the-point pressing, rolling, rotating manipulation used to massage Fengchi, Dazhui acupoints and soft tissue focus in neck area, traction of cervical vertebrae and massage of pain areas, plucking and pressing, two-point and one-site reposition maneuver, once/d; 3 mo Drop outs: NR CG (n = 50) – Massage only: Same as IG; Drop outs: NR | Outcomes (describe instrument used): Pain: NA Disability: NA Results: Baseline: Pain: NA Disability: NA Immediate post tx: Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: TR Cure rate: Post tx: 16 vs. 10 Effective rate: Short term: NR (49/50) 98% vs. (41/50) 83%, p < 0.05 Intermediate: NR Long term: NR Harms: NR Summary: Dose and frequency of tx unclear
Shang, Xiu-kui (2002)218 Country: UK Quality score: /13 Initial of reviewer: SG | Trial Design RCT Tx duration: 54 ds Fu duration (last assessment): immediate post-tx N screened: NR N randomized: 80 N completed tx: 80 N attended last fu: 80 Inclusion: Diagnostic as nerve-toot cervical spondylopathy using Chinese Medical Diagnostic Standard Exclusion: NR | Mean age (SD/range): NR % of male: NR Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Spondylosis Duration of Pain, mean (SD/range): Mixed (acute – chronic), NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 50)– Acu, acupoint Sitianxue: tianyong, tianrong, tianchuan, tianding, and liequan for major acupoints, all points on affected side for cold dampness, add dazhui and fengmen for qi stagnant, add xuehai add touzhui and houxi for headache add jianzhongshu and jianwaishu add shenmai for neck rot limitation add kenlun for pain in lumbar sacrum, 40-50mm, retention 30min; 1 tx/2 d, 9 tx/course, 3 courses Drop outs: A = NR, B =0 CG (n = 30) – Acu acupoint Jiajixue; retention 30 min; Same as IG Drop outs: A = NR, B =0 | Outcomes: Pain: pain score instrument not mentioned (%) Results: Baseline: Pain: IG = 0.8 (0.03), CG = 0.79 (0.04) Immediate post tx: Pain: IG = 0.1 (0.02); CG = 0.32 (0.03) Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: Score based on Chinese Medical Diagnostic and Effective Standard Results- mean: Baseline: IG = 0.62 (0.04), CG = 0.65 (0.03) Immediate post tx: IG = 3.31 (0.01), CG =3.4 (0.05) N (%) improved: IG = 46 (92), CG = 21 (70) Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: IG as main therapy has a marked effect on spondylopathy. This study found the effect of the tx is better with the younger 20 - 40 yr pts than the older pts > 40 yrs
Wang, Xi-Lin (2008)227 Country: China Quality score: 4/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 30 ds Fu duration (last assessment): immediately post-tx N screened: NR N randomized: 102 N completed tx: 102 N attended last fu: 102 Inclusion: NP, neck PPT and/or radiating pain towards chest, shoulder, back, and upper limb, upper limb and figure numb, neck stiff and ROM reduced; Lasègue sign (-); CT or MRT indicate deficits on cervical discs Exclusion: NR | Mean age (SD/range): IG = 43.3 (13.3) vs. CG = 45.2 (14.1) yrs % of male: IG = 49%, CG = 52.9% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Disc/joint disease, degenerative disease Duration of Pain, mean (SD/range): Unknown (mixed), IG = 2.8 (1.62) yrs; CG = 3.1 (1.71) yrs Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 51)– Shu-needling + elecro-acu: GV14, S13, TE5, & EX-B2 were selected, needles were deeply inserted into the cervical vertebrae of corresponding Jiaji (EX-B2), until “deqi” sensation reached, connected with G 6805 electrical impulse device and stimulated at freq. of 3.3 Hz, needle retention for 30 min.; 30min/tx, 1 tx/d, 10 d/period, 30 d total Drop outs: A = 0, B = 0 CG (n = 51) – Routine needling + electro-acu: same acupoints as IG and routine needling applied, tx duration, needle retention and electrical impulse and freq. same as IG; saem as IG Drop outs: A = 0, B = 0 | Outcomes: Disability: NR Results: Baseline: Disability: --- Immediate post tx: Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Efficacy of TCM diagnostic criteria: Immediate post tx: cure rate IG = 68.6, CG = 47.1 ; effective IG = 29.4, CG =37.2; ineffective IG = 2, CG = 15.7 total efficacy (%)IG = 98, CG = 84.3 Short term: NR Intermediate: NR Long term: NR Harms: NR
Zhang, B (2005)228 Country: China Quality score: 0/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 3 wks Fu duration (last assessment): 3 mos N screened: NR N randomized: 96 N completed tx: NR N attended last fu: NR Inclusion: NR (appears to include pts with cervical spondylosis only) Exclusion: NR | Mean age (SD/range): NR % of male: IG = 65.63%, CG = 56.25% Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: 4 Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Cervical spondylosis Duration of Pain, mean (SD/range): Mixed, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 64) – Acupuncture + Massage / Manipulation:. Acupoint injection - Fengchi (GB 20), bilaterally, Ashi points (spot of tenderness or node), 1 to 2; Drugs: VB12500ug (1 ml), Danshen injection 2 mL (1 g/mg), 2 % lidocaine 1 ml. The above drugs were drawn into a one-off 5ml syringe. the doctor inserted the needle into the points and injected the same amount of drugs into each point. If there was no bleeding, the needle was withdrawn with the arrival of qi; 3 tx/wk for 3 wks Drop outs: NR CG (n = 32) – Massage: As IG; Same as IG Drop outs: NR | Outcomes (describe instrument used): Pain: NA Disability: NA Results: Baseline: Pain: NA Disability: NA Immediate post tx: Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Cure rate: Immediate post tx: 81.25% vs. 56.25, p < 0.05 Total effective rate were similar in two grps Short term: NR Intermediate: NR Long term: NR Harms: NR
Zhang, Honglai (2003)85 Country: China Quality score: 6/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 45 ds Fu duration (last assessment): NR N screened: unknown N randomized: 120 N completed tx: 120 N attended last fu: NR Inclusion: diagnosed as Cervical Spondylosis using ref [1] 1993-chinese, Special attention (only those who were compliant with the tx, only those who responded to the surveys) Exclusion: acute external injury cause, not compliant | Mean age (SD/range): NR % of male: IG = 53.3%, CG = 55% Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Spondylosis Duration of Pain, mean (SD/range): Chronic, IG = 81.9 mo, IG2 = 92.2 mo, CG = 91.1 mo Severity of pain (Grading): McGill, VAS Current tx/ co-intervention common in all groups: NR | Groups IG (n = 60)– Electro-acu: tianzhu, jinbailao and dashu (two sides) for major acu points dazhui, fengchi, fengmen, jianjin and waiguan for wind dampness quchi, pishu, fenglong, geshu for tanyuzhu type ganshu, pishu, and zusanli for qi stagnant type ganshu, pishu, zusanli for qi and blood stagnant type yanglao, ganshu, shenshu and taixi for liver and kidney debility. 1.5 Chinese inch, size 30 needle, freq. 120-250/min, retention 30min; 1 tx/d, 15 tx/course, 3 courses, 2 d rest between courses Drop outs: A = NR, B= 0 CG (n = 60) – Traction: 30 min, average traction = 7.5kg; Same as IG Drop outs: A = NR, B= 0 | Outcomes: Pain: McGill PRI total; difference between baseline and fu on VAS Results: Baseline: Pain: IG = 8.57 (2.33), CG = 8.61 (2.42); NR Immediate post tx: Pain: IG = 6.73 (2.12), CG = 7.55 (2.28); IG = 4.87 (1.67), CG = 3.56 (1.26) Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: Cure, improved, effective, no effect n(%) Results- mean: Baseline: Immediate post tx: IG = 56 (93.3%), CG = 47 (78.3%) Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: IG in therapeutic effect and improvement of pain for cervicalspondylosis is better than the CG. This study found that both tx have better effect with younger pts compared with older pts
Zhu, HZ (2006)224 Country: China Quality score: 4/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 18-45 ds Fu duration (last assessment): 6 mos N screened: 221 N randomized: 221 N completed tx: 221 N attended last fu: 221 Inclusion: cervical sponsylosis, 18-75 yrs of age Exclusion: Operation; pregnant and breast-feeding women; Cervical TB, tumor and inflammation; Mental | Mean age (SD/range): IG = 46.04 (9.2) vs. CG = 46.5 (10.3) yrs % of male: IG = 48.7%, CG = 52.8% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Cervical spondylosis Duration of Pain, mean (SD/range): Mixed, IG = 4.59 (3.06) yrs; CG = 4.82 (3.25) yrs Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 115) – Needle-knife: needle-knife therapy at the apper and lower interspinal ligaments of the affected vertebaral body and bilateral pasterior joint capsules; 1 time/3-5 d x 3 times/3 course Drop outs: D = 0 CG (n = 106) – Acupuncture: acu at Luozhen, Ashi and Jiaji points; 1 time/2 d x 5 times/3 course Drop outs: | Outcomes: Pain: NR Results: Immediate post tx: Pain: NR Short term: NR Intermediate: NR Long term: NA | Outcomes (describe instrument used): QoL/ well being: Therapeutic effect Results- mean: Baseline: NA Immediate post tx: NA Short term: IG = 91.3%, CG = 59.4% Intermediate: IG = 94.7%, CG = 56.6% Long term: NR Harms: NR
Zhuang, Li-Xing (2004) 222 Country: China Quality score: /13 Initial of reviewer: NH (Chinese extractions) | Trial Design RCT- Double blind/cross over Tx duration: 3 wks Fu duration (last assessment): N screened: NR N randomized: 34 N completed tx: 34 N attended last fu: 34 Eligibility criteria:; - inclusion: diagnosed as vertebral artery type of cervical spondylosis by western medicine, age 36-72, duration 1 mos-5yrs also diagnosed by chinese medicine; - exclusion: diagnosed as shi zheng | Mean age: IG1 = 53.7 (11.9), IG2 = 53.3 (11.7) % of male: IG1 = 35.3%, IG2 = 23.5% Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP-specific Duration of Pain: IG1 = 2.9 (1.12), IG2 = 2.78 (1.09) Duration of pain: 1 mos-5yrs Severity of pain (Grading): NR | Groups IG1 (n=17) – pressed acu at the baihui acupoint + local electro-acupuncture , retention 30 min, by trained professionals 1tx/day, 7tx/course, total of 3 courses 0 dropouts IG2 (n=17) – local electro-acupuncture by trained professionals, 1tx/day, 7tx/course, total of 3 courses 0 dropouts | Outcomes: Pain: NR Disability: NR Results: Baseline: NA Short Term Follow Up: NA | Outcomes: Curative effect immediately pos-tx:Number of patients cured: 9/17 vs. 4/17 Number of patients with significant effect: 6/17 vs. 4/17 Number of patientswith improvement: 2/17 vs. 7/17 Number of patients without effect: 0/17 vs. 2/17 Other outcomes: chages of contents of plasma thromboxane and 6-keto-prostaglandin 1 alpha and the ratio of these two Harms: NR

Table 2.6 Neck Pain - Acupuncture - Mixed Duration of Disorder - Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other outcomes; Harms
Fu ZH (2007)229 Country: China Quality score: 4/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 24 hours Fu duration (last assessment): immediate post-tx N screened: NR N randomized: 47 N completed tx: 47 N attended last fu: 47 Inclusion: Presence of a tender spot associated with movement of a local muscle, reproduction of clinical symptoms by pressing the MTP, presence of palpable taut band peripheral to the MTP, restricted ROM in the related joint, 18 yrs ≤ age ≤ 80 yrs, TP in the neck/upper back 10 d < duration < 1 yr Exclusion: Pregnancy, history of fractures, surgery of the cervical spine, taking analgesic drug and accepting other txs within 1 wk | Mean age (SD/range): NR % of male: IG1 = 41%, IG2 = 24% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Region of pain: NP/Upper back Cause of Pain: N-S Duration of Pain, mean (SD/range): Mixed (Acute/Sub-acute) Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = 22)– acu insertion along the muscle fiber towards TPs needles moved smoothly and rhythmically from one side to another 200 times in 2 min horizontally, needle remained under skin for 8-24 hrs; one 24 hr tx Drop outs: NR IG2 (n = 25) – acu insertion across the muscle fibers towards TPs ; same as IG1 Drop outs: NR | Outcomes (describe instrument used): Pain: MRP (MRP); PUP (PUP) Results: Baseline: MRP IG1 = 6.05 (2.44), IG2 = 5.32 (2.14) PUP IG1 = 6.23 (1.69), IG2 = 6.16 (1.25) Immediate post tx: MRP IG1 = 3.59 (1.89), IG2 = 2.76 (1.88) PUP IG1 = 3.82 (1.33), IG2 = 3.28 (1.06) Short term: NR Intermediate: NR Long term: NA | Outcomes (describe instrument used): QoL/ well being: NR Cervical ROM: Immediate post tx: 1.36 (0.90) vs. 1.12 (0.88), p = 0.38 Short term: NR Intermediate: NR Long term: NR Harms: NR

Table 2.7 Neck Pain - Acupuncture – Unknown duration of disorder - Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other outcomes; Harms
Duann, J (2006) 231 Country: Taiwan Quality score: /13 Initial of reviewer: NH | Trial Design RCT- Double blind/cross over Tx duration: 1 treatment, 30 mins Fu duration (last assessment): 3 mo N screened: NR N randomized: 72 N completed tx: 72 N attended last fu: NR Eligibility criteria:; - inclusion: Cervical myofascial pain syndrome; - exclusion: NR | Mean age (SD/range): NR % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: Superior Trapezius Cause of Pain: % NS: NR % S: NR Duration of Pain, mean (SD/range): NR Severity of pain (Grading): Nr Current treatment/ co-intervention common in all groups: NR | Groups IG1 (n=36) – Miniscalpel-needle (MSN) treatment on most painful trP, provider NR, inserted for 30 sec, observed for 30 mins, 1 tx total IG2 (n=36) – Lidocaine trP treatment, provider NR, observed for 30 mins 1 tx total | Outcomes: Pain: VAS (0-10), reported as mean for 4 time points Disability: NR Results: Baseline: IG1 = 5.5, IG2 = 5.3 Immediate post tx: IG1 = 3.5, IG2 = 4.1 Short term: IG1 = 2.9, IG2 = 5.0 Intermediate: IG1 = 2.8, IG2 = 4.97 note**these results were not in the extraction form, they were taken (aug.4) directly from a graph | Outcomes: QoL/ well being: NR Other: NR Results- mean : NR Baseline: NA Immediate post tx: NA Short term: NA Intermediate: NA Long term: NA Harms: NR
Edwards J (2003)235 Country: UK Quality score: 6/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 3 wks Fu duration (last assessment): 3 mos N screened: 66 N randomized: 40 N completed tx: 40 N attended last fu: 40 Inclusion: Pts aged ≥ 18 yrs with active MTPs, consent and compliance In place Exclusion: acute condition requiring Tx before 6 wks; skin lesion infection or inflammatory oedema at MTP site; needle phobia; previous adverse reaction to Acu or anaesthetic; serious neurological or systemic disease | Mean age (SD/range): IG = 57 (12), CG1 = 55 (17), CG2 = 57 (19) yrs % of male: IG = 29%, CG1 = 39%, CG2 = 24% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: S Duration of Pain, mean (SD/range): Unknown, IG1 = 16 (23) mo; IG2 = 10 (12) mo; CG = 16 (19) mo Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 14)– Acu + SDN + stretching EX: Before SDN was done, the MTPs were palpated and marked at each session, then needled in turn, working from proximal to distal, needles used: 25 x 0.30 mm with coiled copper handles and plastic guide tubes, needles inserted to depth of 4 mm, retained for avg of 3.4 min; stretching EXs 3 times/d, 3 wks Drop outs: 0 CG1 (n = 13)– Stretching EX: pts received instruction for stretching EXs recommended by Simons et al for involved muscles containing MTPs; 3 times/d, 3 wks Drop outs: 0 CG2 (n = 13) – No tx: NA; NA Drop outs: 0 | Outcomes: Pain: SFMPQ; PPT Results: Baseline: Pain: IG = 24.3 (6.3), CG1 = 23.1 (7), CG2 = 20.2 (8); IG = 1.4 (0.9), CG1 = 1.7 (1), CG2 = 1.4 (1) Immediate post tx: Pain: IG = 13 (10.2), CG1 = 17.1 (9.4), CG2 = 16.5 (10.2); IG = 1.8 (1), CG1 = 1.8 (1), CG2 = 2 (1.4) Short term: IG = 9.1 (11.6), CG1 = 15.2 (8.8), CG2 = 14.9 (11); IG = 2.7 (1.4), CG1 = 1.8 (0.9), CG2 = 2 (1.6) Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: No AEs were reported by pts or observed by therapists in any grps
Fu, W (2005)234 Country: China Quality score: 3/13 Initial of reviewer: SG | Trial Design RCT Tx duration:4 wks Fu duration (last assessment): immediate post-tx N screened: 178 N randomized: 158 N completed tx: 158 N attended last fu: 158 Inclusion: Using both Western Medical and Chinese Medical Diagnostic Standards to Diagnostic Exclusion: Caused by acute external injury; Spinal cord cervical spondylosis ; Pregnant; Heart, liver, or kidney disease | Mean age (SD/range): IG1 = 35.13 (8.88), IG2 = 35.24 (4.67), IG3 = 34.2 (6.67) yrs % of male: IG1 = 53.6%, IG2 = 55.3%, IG3 = 56.4% Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Spondylosis Duration of Pain, mean (SD/range): Unknown, IG1 = 5.7 (4.67), IG2 = 6.05 (4.35), IG3 = 6.15 (5.35) Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = 56)– Needle picking acu: acupoints: bailao(two sides), dazhui, jianjing (two sides), xinshe (two sides), dashu (two sides) 0.1 ml anesthesia, pick skin 0.2 cm; 2 tx/wk, 4 wks Drop outs: B = 1, and 2 changed to other tx IG2 (n = 47) – Local anesthesia: under the acupoint, 0.1 ml anesthesia; Same as IG1 Drop outs: B = 0 IG2 (n = 55) – Normal acu: acupoints as IG1, normal puncture; Same as IG1 Drop outs: B = 0 | Outcomes: Pain: PRI Results: Baseline: Pain: IG1 = 8.91 (4.92), IG2 = 11.85 (2.77), IG3 = 11.64 (3.81) Immediate post tx: Pain: IG1 = 0.36 (0.55), IG2 = 6.91 (3.22), IG3 = 5.71 (2.49) Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: Well being, scoring based on Chinese paper ref [1] n (%) Other: Results- mean: Baseline: --- Immediate post tx: IG1 = 53 (94.6%), IG2 = 47 (100%), IG3 = 55 (100%) Short term: NR Intermediate: NR Long term: NR Harms: CG: n = 1 too much to continue tx; n = 2 scarring after tx (switched tx groups-unknown which group) Summary: sign. difference between 3 groups
Liang, ZH (2009)230 Country: China Quality score: /13 Initial of reviewer: SG | Trial Design RCT Tx duration: single 20 min session Fu duration (last assessment): NR N screened: NR N randomized: 106 N completed tx: NR N attended last fu: NR Inclusion: NP caused by cervical spondylosis Exclusion: NR | Mean age (SD/range): NR % of male: NR Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Cervical spondylosis Duration of Pain, mean (SD/range): Unknown, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 53)– Acupuncture: acu points at Daahui (GV14), Jingbailao (Ex HN15), and Jianzhongshu, + infrared; single session, 20 min needle retention Drop outs: NR CG (n = 53) – Sham-acu: sham acu at 1 cm lateral to Bailao and Jianzhongshu points + infrared; Same as IG Drop outs: NR | Outcomes (describe instrument used): Pain: NR Disability: NA Results: Baseline: Pain: NA Disability: NA Immediate post tx: Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Effective rates: Immediate post tx: 75.5% vs. 52.8%, p < 0.05 Nordic Pain questionnaire:, mean SD: 19.16 (11.49) vs. 23.76 (12.15) Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: acu had better therapeutic effects than sham acu in pts isth cervical spondylosis.
Wang, XL (2007)233 Country: China Quality score: 3/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 30 ds Fu duration (last assessment): immediate post-tx N screened: NR N randomized: 120 N completed tx: 120 N attended last fu: 120 Inclusion: diagnosed as Cervical Spondylosis according to “Chinese medicine clinical research guiding principles” Exclusion: NR | Mean age (SD/range): IG1 = 46.3 (NR) vs. IG2 = 49.2 (NR) yrs % of male: IG1 = 60, IG2 = 48.3% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Disc/joint disease Duration of Pain, mean (SD/range): Unknown, IG = 3.9 yrs; CG = 4.2 yrs Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = 60)– Needle retention at GV 20 for 8 hrs and electro-acu at local points: GV 20 and 4 other acupoints selected, needles inserted until “deqi” sensation reached, needle at GV20 remained for 8 hrs, other needles connected with G6805 electrical impulse device, retention time 30 min.; 1 session/d, 30 sessions total Drop outs: A = 0, B = 0 IG2 (n = 60) – Needle retention at GV 20 for 30 min. and electro-acu at local points: GV 20 retention time is 30 min. rest of tx same as IG1; same as IG1 Drop outs: A = 0, B = 0 | Outcomes (describe instrument used): Pain: NR Disability: NA Results: Baseline: Pain: NR Disability: NA Immediate post tx: Pain: NR Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: Other: Cure rate; sign. Effective; effective; ineffective; total efficacy (%) Results- mean: Baseline: Immediate post tx: IG = 70, CG = 45; IG = 18.3, CG = 26.7; IG = 10, CG = 15; IG = 1.7, CG = 13.3; IG = 98.3, CG = 86.7 Short term: NR Intermediate: NR Long term: NR Harms: NR
Zheng, Ling (2005)232 Country: China Quality score: 5/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 30 ds Fu duration (last assessment): NR N screened: not mentioned N randomized: 60 N completed tx: 60 N attended last fu: NR Inclusion: Diagnostic as cervical spondylopathy by ref [1]-A Chinese paper; No surgery; coronary heart disease, rheumatism etc. Exclusion: NR | Mean age (SD/range): IG = 52.5 (11.9) vs. CG = 51.24 (11.5) yrs % of male: NR Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Spondylosis Duration of Pain, mean (SD/range): Unknown, IG = 5.2 (3.65), CG = 4.9 (2.34) Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 30)– Point-through-point acu: acupoints: fengchi through fengfu, tianzhu through jiaji, neck jiaji through transverse oscillatory rot to bottom, dashu through breast, jiaji, houxi through laogong, xuanzhong through sanyinjiao 40-100mm long needle, retention 30 min; 1 tx/d, 15 tx/course, 2 courses, 3 ds rest between courses Drop outs: A = NR, B= 0 CG (n = 30) – General acu: acupoints: fengchi, fengfu, tianzhu, neck jiaji, dashu, houxi, juegu and sanyinjiao 40-100mm long needle, retention 30 min; Same as IG Drop outs: A = NR, B= 0 | Outcomes (describe instrument used): Pain: N of pts who has pain (binary variable- not recorded) Results: Baseline: Pain: --- Immediate post tx: Pain: --- Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: Well being: scoring based on Ref[1] as well: Improved = cure + better; Cure n (%) Other: Results- mean: Baseline: Immediate post tx: IG = 30 (100%), CG 30 (100%); IG = 19 (63.3%, CG = 8 (26.7%) Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: The effects were significantly better in IG

Table 2.8 Neck Pain - Acupuncture - Unknown - Non-Specific Pain – No studies

Table 2.9 Neck Pain - Manipulation & Mobilization Therapies - Acute - Specific Pain – No studies

Table 2.10 Neck Pain - Manipulation & Mobilization - Acute - Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other outcomes; Harms
Buhmann, J (2005)236 Country: Germany Quality score: 7/13 Initial of reviewer: SG | Trial Design-RCT- Tx duration: NR Fu duration (last assessment): 24 hrs post last tx N screened: 60 N randomized: 26 N completed tx: 24 N attended last fu: NR Inclusion: 18-80 yrs, manually diagnosed dysfunction of one or both of the segments occiput/cervical 1 and cervical 1/cervical 2 Exclusion: previous surgery of cervical spinal column, arthrosis of cervical spinal column, spondylolisthesis, fracture, inflammation, previous disk herniations or cervical spinal column, any kind of cancer or planned surgery in throat, neck or head region; acute painful dysfunctions in locomotor system; currently undergoing chiropractic tx | Mean age (yrs) (SD/range): IG = 44 (22), IG2 = 46 (14), CG = 49 (7) % of male: IG = 60%; IG2 = 62%; CG = 50% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: NR Duration of Pain, mean (SD/range): Acute/Sub-acute NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = 10) – SM: thrusting force on lateral aspects of occiput or C1 exerted for < 200 msec before and after anesthesia; NR Drop outs: A = 0, B = 2 IG2 (n = 8) – Post-isometric relaxation): applied to hypertonic muscle - isometric contraction by pts against manual resistance for 10 sec then stransverse oscillatory rotped and repeated after at least 20 sec rest with increasing anti-flx/ retro-flx or later flx; before and after anesthesia NR Drop outs: See IG1 CG (n = 8) – Placebo: Laying palms of clinician on sides of pt's neck without any side-different pressure or without having pt under tension; before and after anesthesia NR Drop outs: See IG1 | Outcomes: Disability: N of found dysfunctions in motion segments O/C1 and C1/C2-no numerical data is reported (only p values) Results: Baseline: Disability: IG1 = 21, IG2 = 15, CG = 13 Immediate post tx: Disability: --- Short term: NR Intermediate: NR Long term: NA | Outcomes: QoL/ well being: NR Results- mean: Immediate post tx: Short term: NR Intermediate: NR Long term: NA Harms: 2 WDAE in IG1- complication arising from a surgical operation Summary: sig effect of IG1&2 vs. placebo, in restoring function (p< 0.01) In anesthesia: IG1 vs. placebo, p < 0.01. No sig difference between IG1 & 2 (P = 0.137). The tx effect postnarcotically was further sign in IG1 vs. placebo only (P = 0.011
Gonzalez-Iglesias, J (2009)239 Country: Spain Quality score: 9/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: 3 wks Fu duration (last assessment): 2 & 4 wks after last tx N screened: 60 N randomized: 55 N completed tx: 55 N attended last fu: 55 Inclusion: 18-45 yrs of age with mechanical NP less than 1 mo duration Exclusion: contraindication to manipulation; history of whiplash or cervical surgery; diagnosis of cervical radiculopathy or myelopathy; fibromyalgia; spinal manipulative therapy in prior 2 mo | Mean age (SD/range): IG = 34 (4) vs. CG = 35 (6) yrs % of male: IG = 52.2%; CG = 54.5% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Acute, IG = 18.7 (3.9) ds, CG = 19.5 (4.5) ds Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | IG (n = 23) – Electro/thermal therapy with thoracic spine thrust manipulation: superficial thermal and electrotherapy: infrared lamp (250W) 50cm from neck applied for 15 minutes; followed by trans-cutaneous electrical nerve stimulation at 100Hz for 20 min using two 4x6cm electrodes bilaterally on each side of spinous process of C7 vertebra + seated “distraction manipulation in upward motion, 2^nd^ manipulation applied if no popping, Max of 2 attempts; 5 electro/thermal sessions over 3 wks, 3 min. sessions Drop outs: A = 0, B = 0, C = 0 CG (n = 22) – Electro/thermal therapy: As IG; 5 sessions, 3 wks Drop outs: A = 0, B = 0, C = 0 | Outcomes: Pain: 100 mm VAS Disability: Northwick park questionnaire Results: Baseline: Pain: IG = 54.7 (8.2), CG = 52.7 (5.5) Disability: IG = 27.9 (3), CG = 27 (3.1) Immediate post tx: Pain: IG = 20.2 (7.8), CG = 44.7 (5.5) Disability: IG = 15.2 (3.9), CG = 23.1 (3.2) Short term: Pain: IG = 26.4 (11.8), CG = 41.2 (6.1) Disability: IG = 14.7 (2.8), CG = 21.8 (3.3) Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR
Pikula, J (1999)237 Country: Canada Quality score: 4/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: One session Fu duration (last assessment): Immed. Post-tx N screened: 36 N randomized: 36 N completed tx: NR N attended last fu: NR Inclusion: 1^st^ acute (< 2 wks)unilateral NP, no hx of trauma, neurological deficit, or previous chiropractic tx of the cervical spine Exclusion: Radiculitis or pain into the arm or hand, neurological deficis of he brachial plexus roots, hx of fracture/ tumour/ infection/ spondyloarthropathy, px cervical SM tx pervious neck surgery, workers' compensation or disability insurance issues, conditions potentially aggravated by electrical devices (i.e. pacemaker) | Mean age (SD/range): IG1 = 39.5 (5.92), IG2 = 42.6 (7.78), CG = 44.2 (6.98) yrs % of male: IG1 = 33%, IG2 = 8%, CG = 25% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Acute, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = 12)– SM applied to painful side (ipsilateral): supine position, open hand contact 2^nd^ finger placed adjacent to the articular pillars of the mid cervical spine. Head rotated contra laterally & slightly extended passively to max ROM. HVLA thrust applied and an audible crack was heard; one tx Drop outs: NR IG2 (n = 12)– SMT applied to opposite of painful side (contra lateral): same as IG1; As IG1 Drop outs: NR CG (n = 12) – Placebo ultrasound therapy: Transducer head applied in gradual circular movement stimulating a tx; one 8 min tx Drop outs: NR | Outcomes (describe instrument used): Pain: VAS 100 mm (0-100) Disability: NR Results: Baseline: Pain: IG1 = 42.5 (19.8), IG2 = 44.1 (27.5), CG = 50.4 (22.5) Disability: NR Immediate post tx: Pain: IG1 = 23.6 (18.6), IG2 = 41.4 (28.4), CG = 46.5 (21.8) Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR CROM-cervical ROM Immediate post tx: flx: 58.8 (15.6) vs. 49.8 (14.6) vs. 46.0 (11.4) Extension: 57.3 (11.3) vs. 46.0 (12.0) vs. 48.2 (15.9) Ipsilateral rot: 612 (9.7) vs. 53.8 (9.1) vs. 49.8 (19.7) Short term: NR Intermediate: NR Long term: NR Harms: NR
Yurkiw, D (1996)238 Country: Canada Quality score: 7/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: One session Fu duration (last assessment): Immed. Post-tx N screened: NR N randomized: 14 N completed tx: 14 N attended last fu: 14 Inclusion: Unilateral NP of at least 3 wks duration between ages of 18 and 55 yrs Exclusion: individuals with any SM during previous 90 ds; severe pathology, infection or suspected of malingering | Mean age (SD/range): NR % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Acute/Sub-acute, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 7)– Diversified SM: area of tx restricted to lower cervical spine, Sally one vertebral level from the 3^rd^-7^th^ vertebrae inclusive; tx performed according to accepted methods described by Haldeman and also Koes et al who allowed therapy to be at the discretion of provider, although choices limited to two types of procedure described by Haldeman; 1 tx Drop outs: NR CG (n = 7) – Mechanically assisted manipulation: As IG as described by Petterson, applied in prone position with instrument at “2 ring” position, one “click” application given; 1 tx Drop outs: NR | Outcomes: Pain: 10 cm VAS Disability: Results: Baseline: Pain: IG = 32.857 (25.777), CG = 32.857 (17.874) Immediate post tx: Pain: IG = 21.857 (21.459), CG = 20.427 (18.402) Disability: Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Other: ROM with Goniometer: Right lateral flx; left lateral flx Immediate post tx: Right lateral flx IG = 34.429 (3.599), CG = 44 (8.583); left lateral flx IG = 5.843 (5.5), CG = 10.25 (5.537) Short term: NR Intermediate: NR Long term: NR Harms: NR

Table 2.11 Neck Pain - Manipulation & Mobilization - Chronic - Specific Pain – No studies

Table 2.12 Neck Pain - Manipulation & Mobilization - Chronic - Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other outcomes; Harms
Bischoff, A (2003)243 Abstract Country: NR Quality score: 1/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 10 wks Fu duration (last assessment): Immed. Post-tx N screened: 135 N randomized: 49 N completed tx: 42 N attended last fu: 42 Inclusion: Chronic N-S NP Exclusion: NR | Mean age (SD/range): NR % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 24)– Sham ultrasound + Osteopathic intervention: 12 min session of sham ultrasound every wk for 10 wks + test-dependent osteopathic intervention every other wk; 1 tx/wk for 10 wks Drop outs: A = 0, B = 1 CG (n = 25) – Sham ultrasound: 12 min session of sham ultrasound; 1 tx/wk for avg of 10 wks Drop outs: A = 0, B = 6 | Outcomes (describe instrument used): Pain: Avg pain intensity-NRS (0-10) Results: Baseline: Pain: IG = 4.7, CG = 4.8 Immediate post tx: Pain: IG = 2.2, CG = 4 Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Results- mean: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: On the NRS, average pain intensity decreased significantly in the osteopathic group (p<0.0005) but not the sham group (p=0.09)
Chen, L (2007)244 Country: China Quality score: 7/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 20 ds Fu duration (last assessment): 3 mos N screened: 75 N randomized: 70 N completed tx: 70 N attended last fu: 70 Inclusion: Cervicogenic headache; Disease course > 6 mo; without drug therapy in 3 mo; X-ray has positive discover Exclusion: Other type of headache; after neck operation; Severe osteoporosis | Mean age (SD/range): IG = 41.32 (11.27) vs. CG = 43.68 (16.63) yrs % of male: IG = 44.4%, CG = 70.6% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic (>6 mo) IG = 24.34 (6.62); CG = 18.51 (8.43) Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 36) – Spinal manipulation: NR; 20-30 min/2 ds, 10 tx, Drop outs: A = 2, C = 3 CG (n = 34) – TENS: Pre-medic electrotherapy machine (German); 100 Hz, 20 min/2 ds, 10 tx Drop outs: unclear | Outcomes: Pain: NRS Headache frequency, and lasting time- data not shown) Results: Baseline: Pain: IG = 7.45 (1.22), CG = 7.86 (1.34) Immediate post tx: Pain: NR Short term: IG = 2.81 (1.15), CG = 5.26 (1.83) Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Response rate (%) Immediate post tx: 94.5% vs. 64.5%, p < 0.05 Short term: NR Intermediate: NR Long term: NA Harms: NR
Cleland, J (2005)242 Country: US Quality score: 7/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: One session Fu duration (last assessment): Immed. Post.tx N screened: 68 N randomized: 36 N completed tx: 36 N attended last fu: 36 Inclusion: 18-60 yrs with primary complaint of mechanical NP, referred by primary care physician to outPt orthopaedic physical therapy clinic Exclusion: red flags; pregnancy; with positive neurologic signs or symptoms suggestive of nerve root involvement, history of cervical or thoracic surgery; hypermobility of thoracic spine; prior experience with spinal manipulative techniques | Mean age (SD/range): IG = 36 (8.5) vs. CG = 35 (11.3) yrs % of male: IG = 26.3%, CG = 23.5% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S, Mechanical Duration of Pain, mean (SD/range): Unknown or mixed, IG = 12.2 (3.5) wks, CG = 13.2 (4.2) wks Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: None | Groups IG (n = 19)– Thoracic spine manipulation: thoracic manipulation directed to identified segmental mobility restrictions (performed in positions of thoracic spine flx and ext); 1 tx Drop outs: A = 0, B = 0 CG (n = 17) – Placebo (manipulation): stabilizing open hand placed over inferior vertebrae of pre-determined segmental restriction; when pre-manipulative position achieved, pt instructed to take deep breath and exhale, with no intervention during exhalation; As IG Drop outs: A = 0, B = 0 | Outcomes: Pain: 100 mm VAS to assess resting pain Disability: NDI to assess perceived disability due to NP Results: Baseline: Pain: IG = 41.6 (17.8), CG = 47.7 (18.4) Disability: IG = 28.4 (11.9), CG = 33.6 (14.2) Immediate post tx: Pain: IG = 26.1 (17.2), CG = 4.5 (19.5) Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: no reporting of any AEs by pts (pts were instructed to contact the investigators if experiencing any AE)
Giles, LG (2003)25,26 Country: Australia Quality score: 5/13 Initial of reviewer: SG | Trial Design- RCT Tx duration: Max. of 9 wks Fu duration (last assessment): 12 mos N screened: 109 N randomized: 109 N completed tx: 109 N attended last fu: 62 Inclusion: pts at least 17 yrs old with uncomplicated mechanical spinal pain for minimum of 13 wks - for long-term fu (> 1 yr) Exclusion: pts with nerve root involvement, spinal anomalies (other than sacralization/lumbarization), pathology other than mild-moderate osteroarthrosis, spondylolisthesis of L5 or S1 > Grade 1, previous spinal surgery, and leg length inequality > 9 mm with postural scoliosis. | Mean age (SD/range): IG1 = 23.8 (4.8), IG2 = 25 (8.1), CG = 29.5 (2.07) yrs % of male: IG1 = 55.9%, IG2 = 51.4%, CG = 57.5% Racial composition: NR Work status: NR Other socio-demographics: Unemployed: 29 (25.7%) Co morbidities: NR Prior episode of pain if acute: NA Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: LBP, NP, thorax Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic (> 13 wks), NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = 34)– Acu: near and far techniques as chosen by clinician; 2 tx/wk, max. of 9 wks Drop outs: B = 12 IG2 (n = 35)– Spinal manipulation: 20 min-appointments. High-velocity, low-amplitude thrust SM to a joint (as judged to be safe and usual tx by the treating chiropractor for the spinal level of involvement to mobilize the spinal joints; same as IG1 Drop outs: B = 10 CG (n = 40) – Medication that have not been tried: Celecoxib/Celebrex (200 - 400 mg/d); Rofecoxib/Vioxx (12.5 - 25 mg/d); paracetamol/acetaminophen (500 mg tablest 2-6/dup to 4 g/d); NR Drop outs: B = 18 | Outcomes: Pain: VAS (1-100) Disability: Oswestry Back Results: Baseline: Pain: IG1 = 6 (2.2), IG2 = 6 (2.9), CG = 5 (3.7) Disability: IG1 = 30 (17.03), IG2 = 22 (22.96), CG = 32 (19.3) Immediate post tx: Pain: IG1 = 4 (4.4), IG2 = 5 (3.7), CG = 6 (4.4) Disability: IG1 = 26 (20.74), IG2 = 14 (24.4), CG = 32 (23.7) Long term: OBD: IG1 = 13 (22.9), IG2 = 16 (17.8), CG = 24 (25.2) VAS: IG1 = 3.9 (3.2), IG2 = 3.7 (4), CG = 3.9 (3.3) | Outcomes: QoL/ well being: SF-36 (higher values better) Other: Results- mean: Baseline: IG1 = 46 (15.6), IG2 = 57 (22.9), CG = 37 (25.2) Immediate post tx: IG1 = 53 (22.2), IG2 = 70 (38.5), CG = 57 (33.3) Short term: NR Intermediate: NR Long term: IG1 = 55 (26.7), IG2 = 77 (23.7), CG = 66 (36.3) Harms: NR
Giles, LGF (1999)122 Country: Australia Quality score: 1/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 3-4 wks Fu duration (last assessment): immediate post-tx N screened: 875 N randomized: 40 N completed tx: 40 N attended last fu: 40 Inclusion: pts suffering from spinal pain for at least 13 wks; age of at least 18 yrs Exclusion: Nerve root involvements; spinal anomalities; pathology other than mild to moderate osteoarthrosis; previous spinal surgery and leg length inequality of > 9 mm with postural scoliosis | Mean age (SD/range): IG1 = 46.5 (9.6), IG2 = 42.5 (9.6), CG = 35 (14.1) yrs % of male: 35.7% total Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = 10)– Acu: using sterile HWATO Chinese disposable acu guide tube needles 50mm long with a gauge of 0.25 mm for 20 ?; 6 tx, 3-4 wks Drop outs: NR IG2 (n = 20) – Manipulation: A high-velocity, low-amplitude SM was performed as judged to be safe; 6 tx, 3-4 wks Drop outs: NR CG (n = 10) – Medication: tenoxican (20mg/d) and ranitidine (50mg x 2/ d); 15-20 min/ appointment, 3-4 wks Drop outs: NR | Outcomes: Pain: VAS Disability: ODI Results: Baseline: Pain: IG1 = 40 (31.8), IG2 = 32 (14.8), CG = 28 (21.9) Disability: IG1 = 3.5 (5.5), IG2 = 5 (3.5), CG = 2.7 (4.8) Immediate post tx: Pain-mean change: IG1 = -6 (14.4), IG2 = -10 (10.4), CG = 0 (10.7) Disability-mean change: IG1 = -0.5 (4.8), IG2 = -2.3 (4.8), CG = -1 (1.3) Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR
Haas, M (2004)245 Country: US Quality score: 7/13 Initial of reviewer: SG | Trial Design-RCT- dose response study Tx duration: 3 wks Fu duration (last assessment): 12 wks N screened: 86 N randomized: 24 N completed tx: 23 N attended last fu: 23 Inclusion: 18 yrs of age or older with English literacy and uncomplicated, chronic cervicogenic headache; history of at least 5 cervicogenic headaches/mo for at least 3 mo Exclusion: contrain-dications to SM or complicating conditions potentially related to clinical outcomes: malignancy or history of cancer, spinal infection, vertebral tumors or fracture, lumbar instability, blood dyscrasia, severe trauma within last 3 months. | Mean age (SD/range): IG1 = 38.9 (11.9) vs. IG2 = 46.6 (6) vs. IG3 = 35.4 (9.9) yrs % of male: 27% Racial composition: 82.3% White/Non-Hispanic Work status: NR Other socio-demographics: 47.3% Married Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: Physical modalities; Massage/TP therapy; hot/cold packs | Groups IG1 (n = 8)– SM 3 office visits + massage and other tx: HVLA SM; discretional therapy included administration of up to 2 PM from: heat and soft tissue therapy including massage and TP therapy; recommend modification of daily activity; 1 tx/wk, 3 wks Drop outs: A = 0, B = 4, C = 0 IG2 (n = 8)– Manipulation 9 office visits + massage and other tx: As IG1; 3 tx/wk, 3 wks Drop outs: NR IG3 (n = 8) – Manipulation 12 office visits + massage and other tx: As IG 1; 4 tx/wk, 3 wks Drop outs: NR | Outcomes: Pain: headache (HA); NP (NP) Disability: Modified Von Kroff (MVK) Results: Immediate post tx: HA: 40.5 (15.6) vs. 31.3 (15.6) vs. 18.7 (14.5) NP: 41.9 (11.7) vs. 29.6 (15.6) vs. 22.5 (14.9) MVK-HA: 25.2 (19.7) vs. 18.3 (13.7) vs. 7.9 (10.1) MVK-NP 31.4 (17.7) vs. 22.1 (24.4) vs. 9.8 (12.1) Short term: Pain: HA: 49 (19.8) vs. 34.2 (12.3) vs. 27.9 (30.3); NP: 14.7 (8.9) vs. 11.5 (11.9) vs. 7 (9.8) MVK-HA: 39 (25.8), vs. 17.5 (16.1) vs. 14.6 (27.3) MVK-NP 33.3 (9.6) vs. 14.2 (14.1) vs. 3.7 (20.0) | Outcomes (describe instrument used): QoL/ well being: NR Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: no AEs were reported by pts.
Jull, G (2005)240 Country: US Quality score: 9/13 Initial of reviewer: FY | Trial Design-RCT Tx duration: Fu duration (last assessment): 1 week immediately post tx; 3, 6, and 12 months post tx N screened: NR N randomized: 200 N completed tx: N attended last fu: Inclusion: adults 18 – 60 years with unilateral or unilateral dominant side consistent cervicogenic headaches aggravated by neck postures or movement (presence of joint tenderness as detected by manual palpation)- frequency of headache at least1/week with history of 2 months and 10 years Exclusion: other causes of headache; bilateral headaches; migraine; contraindication for manipulative therapy, or current involvement in third party or workers compensation | Mean age range: 36 – 37 years % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NA | Cervicogenic headaches Duration of Pain, mean (SD/range): NR Severity of pain (Grading): NR Current treatment/ co-intervention common in all groups: NR | IG (n = 51 )– manual therapy: not defined Drop outs: NR IG2 (52): combined manipulative tx and exercise Drop outs: NR CG1 (49): exercise therapy Drop outs: NR CG2 (n = 48)– control: not defined Drop outs: NR | Outcomes: Pain: 1- MPQ/ PRI 2- Headache specific locus of control scale (HSLC) 3- pain produced by active cervical movements by VAS Pain and disability: by Northwick Park Neck Pain questionnaire Main objective: predictors from variables in pts demographics and headache hx of achieving 50-79% or 80-100% reduction in headache immediately post and 12 months post-tx Results: Lightheadedness had higher odds of achieving 50-79% reduction in headache: OR = 5.45 or 80-80% OR = 5.7 at 12 months | Outcomes (describe instrument used): Daily medication intake were measured at baseline (over the counter: anti-inflammatory medications in short and owe doses)—analysed as defined daily does (DDD): data NR Harms: NR Summary: no consistent pattern of prediction of successful outcomes (all demographics including age, gender, family history, pain intensity/ frequency, medication use, associated symptoms, etc)
Nilsson, N (1997)246 Country: Denmark Quality score: 7/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 3 wks Fu duration (last assessment): 3 wks N screened: 450 N randomized: 53 N completed tx: 53 N attended last fu: 53 Inclusion: 20-60 yrs with headache ≥ 5 ds/mo for at least 3 mo; no prior SM in cervical spine; no effect of migraine Med if tried; headache in occipital region, with or without forward radiation; aggravated by neck postures Exclusion: NR | Mean age (SD/range): IG = 42 vs. CG = 35 yrs % of male: IG = 46%, CG = 40% Racial composition: NR Work status: Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic, NR Severity of pain (Grading): IG = 48, CG = 37 Current tx/ co-intervention common in all groups: NR | Groups IG (n = 28) – SM: toggle recoil for upper cervical region and diversified technique for mid and lower cervical, as determined on palpation; in each technique a HVLA thrust in line of drive at end point of normal passive; 2 wk observation period, 6 sessions over 3 wks Drop outs: A = 0, B = 0 CG (n = 25) – Massage: deep friction massage, including TP, of posterior muscles of shoulder girdle, the upper thoracic & lower cervical regions, plus tx with laser light in upper cervical region; laser light added to include an upper cervical intervention; Same as IG Drop outs: A = 0, B = 1 | Outcomes (describe instrument used): Pain: 100 mm VAS- mean intensity of daily headache Results: Baseline: Pain: IG = 44, CG = 41 Immediate post tx: Pain: IG = 28, CG = 36 Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Number of analgesics/d (mean): Baseline: 1.5 vs. 1.0 Immediate post tx: 0.8 vs. 0.7 Short term: NR Intermediate: NR Long term: NR Harms: NR
Sloop, P (1982)241 Country: Quality score: 5/13 Initial of reviewer: SG | Trial Design-RCT- cross over Tx duration: One session Fu duration (last assessment): 3 wks N screened: NR N randomized: 39 N completed tx: NR N attended last fu: NR Inclusion: 19-68 yrs with cervical spondylosis or N-S NP of at least one mo duration; no symptoms suggestive of major systemic disease; no progressive neurlogic signs and no extraneous local cause of symptoms Exclusion: NR | Mean age (SD/range): NR % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: 20mg diazepam intravenously | Groups IG (n = 21)– Manipulation: NR; one tx session, 3 wk fu to assess outcomes Drop outs: NR CG (n = 18) – Control: NR; As IG Drop outs: NR | Outcomes (describe instrument used): Pain: 100 mm VAS (0-100) Results: Baseline: Pain: NR Immediate post tx: Pain-mean change: IG = 18.0 (31), CG = 5.0 (32), p = 0.20 Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR General effective rate (did the tx help you?) Immediate post tx: pre cross over data 21 (57%) vs. 18 (28%) responded yes, p = 0.13 Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: local tenderness at baseline was the only item associated with VAS outcome (p = 0.013)
Sterling, M (2001)248 Country: Canada Quality score: 7/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: one session Fu duration (last assessment): post tx N screened: NR N randomized: 30 N completed tx: NR N attended last fu: NR Inclusion: Pts were included if they had a history of mid to lower cervical spine pain of insidious onset, greater than 3 mo duration and were assessed by a manipulative physiotherapist as having symptoms primarily originating from the C5/6 segment. Exclusion: a history of trauma or surgery to the cervical spine; evidence of referred arm pain or radiculopathy; headache, dizziness or other upper cervical spine symptoms; diabetes or peripheral vascular disease | Mean age (SD/range): 35.77 (14.92) yrs (total) % of male: IG = 47%, CG1 = 53%, CG2 = NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 10)– Spinal Mob: SMT tx (passive Mob) condition, researcher applied a grade III postero-anterior technique to the articular pillar of C5/6 on the subject's symptomatic side (Maitland 1986); one time in a crossover design Drop outs: NR CG1 (n = 10) – Placebo SM: Manual contact was applied over the articular pillar of C5/6 on the symptomatic side but with no movement of the vertebral segment; as IG Drop outs: NR CG2 (n = 10) – Control: no physical contact (no tx); as IG Drop outs: NR | Outcomes (describe instrument used): Pain: Pressure pain threshold (PPT); resting pain (VAS)- result of post hoc analysis reported as comparison if IG vs. CG1 or IG vs. CG2 Disability: NR Results: Immediate post tx: Pain at rest: IG vs. CG1 0.091 ; IG vs. CG2 0.044 Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Other: EMG activity (data not shown) Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR
Whittingham, W (2001)247 Country: Australia Quality score: 8/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 3 wks Fu duration (last assessment): cross over deign-data pre-crossover is shown N screened: NR N randomized: 105 N completed tx: 105 N attended last fu: 105 Inclusion: 16 yrs or older cervicogenic headache with 4 or more ds of headache in 1 mo for more than 6 mo; headache in occipital region, with/without forward projection; headache provoked by neck movements or positions or sub-occipital manual pressure Exclusion: NR - | Mean age (SD/range): 39.4 (12.5) yrs % of male: 40.8% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 55)– Manipulation: manipulation to the cervical spine: single toggle-coil thrust (a short-lever, high-velocity technique) to C1 or C2 as indicated; 3 tx/wk for 3 wks Drop outs: E = 3 CG (n = 50) – Sham manipulation: sham manipulation as IG delivered with deactivated Pettibon instrument; 3 tx/wk for 3 wks Drop outs: NR | Outcomes (describe instrument used): Pain: NR Disability: NR Results: Immediate post tx: Pain: NR Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: Active cervical ROM: Immediate post tx (3 wks): right rot: 57 (1.4) vs. 56 (1.6) Left rot: 55 (1.4) vs. 54 (1.6) Right lateral flextion:37 (1.2) vs. 39 (1.3) Left lateral flextion: 36 (1.4) vs. 38 (1.1) degress Short term: NR Intermediate: NR Long term: NR Harms: NR

Table 2.13 Neck Pain - Manipulation & Mobilization – Mixed - Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other outcomes; Harms
Coppieters, M (2003)250 Country: Belgium Quality score: 5/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: NR Fu duration (last assessment): NR N screened: 20 N randomized: 20 N completed tx: NR N attended last fu: NR Inclusion: Sub-acute (2 wks-6 mo) unilateral (15) or bilateral (5) peripheral neurogenic cervicobrachial pain, presence of a cervical segmental motion restriction related to a neurogenic disorder, adverse response to neural tissue provocation testing, painful nerve trunk palpation, or signs of a local musculoskeletal dysfunction such as cervical segmental motion restriction Exclusion: Neurogenic disorders, such as diabetic neuropathy, that are not amenable to manipulative therapy management | Mean age (SD/range): IG = 49.1 (14.1) vs. CG = 46.6 (12.1) yrs % of male: IG = 20%; CG = 0.2% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: Brachial or Cervicobrachial neurogenic pain Cause of Pain: NR Duration of Pain, mean (SD/range): Mixed, IG = 2.7 mo, CG = 3.2 mo Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 10)– Experimental Mob: Cervical contralateral lateral glide Mob technique applied at 1 or more motion segments (C5-T1) with pt in supine position, most frequent treated spinal levels were C5, C6 and C7 at low frequency; NR Drop outs: NR CG (n = 10) – Control-Ultrasound: Pulsed ultrasound applied over the most painful area; applied for 5 min, dose of 0.5 W/cm^2^, sonation time 20%, size of tx head 5 cm^2^, freq. 1 MHz, sonopulse 590; NR Drop outs: NR | Outcomes: Pain: Pain intensity Results: Immediate post tx: Pain: 5.8 (2.1) vs. 7.4 (1.8) Short term: NR Intermediate: NR Long term: NA | Outcomes: QoL/ well being: NR Range of Motion (ROM) Baseline: 137.3 (15.4) vs. 130.2 (14.7) Immediate post tx: 156.7 (10.7) vs. 130.7 (16.0) Short term: NR Intermediate: NR Long term: NA Harms: NR
Fernandez-de-las-Penas, C (2004)249 Country: Spain Quality score: 6/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 3 wks Fu duration (last assessment): immediately post-tx N screened: 88 N randomized: 88 N completed tx: NR N attended last fu: NR Inclusion: Suffering from neck and head pain due to whiplash injury of less than 3 mo and classified in grades II and III Exclusion: Whiplash injury since 3 mo ago, previous whiplash injury before the study, articular instability, and degenerative cervical alteration | Mean age (SD/range): 31.2 yrs total % of male: 45% total Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: Head and Neck Cause of Pain: Whiplash Duration of Pain, mean (SD/range): Mixed, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 44)– Dorsal manipulation + PT: active EXs, electro-therapy, ultrasound and manual therapy. Dorsal manipulation was performed once at the 5th and 10th sessions. Manual therapy was applied as HVLA technique. A cracking or popping sound accompanied the manipulation; 5 tx/wk, 15 tx, 3 wks Drop outs: NR CG (n = 44) – Physiotherapy: active EXs, electro-therapy, ultrasound and manual therapy, ultrasound in soft tissues of neck region, active EXs at home, muscle stretching and multimodal therapy; As IG Drop outs: NR | Outcomes (describe instrument used): Pain: VAS (0-100) Results: Immediate post tx: Pain reduction one wk after 1^st^ dorsal manipulation cervical pain: 54 vs. 39; TP 143 vs. 32; head pain: NR After 2^nd^ manipulation: cervical pain: 100 vs. 73; TP 238 vs. 59 head pain Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: Dorsal manipulation favors the clinical improvement in whiplash pts. IG had more reduction of symptoms than the CG

Table 2.14 Neck Pain - Manipulation & Mobilization - Mixed - Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other outcomes; Harms
Brodin (1983)259 Country: Sweden Quality score: 3/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 3 wks Fu duration (last assessment): NR N screened: NR N randomized: 63 N completed tx: 55 N attended last fu: NR Inclusion: between 27-60 yrs of age; condition suitable for manual therapy (i.e. possible by means of manual technique to observe restricted movement in pain-producing segment) Exclusion: pain from segments with normal or increased mobility | Mean age (SD/range): NR % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: Cause of Pain: N-S Duration of Pain, mean (SD/range): Mixed, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 23)– Medication: Premaspin 1.5 g + 0.5 g + 0.5 g daily for 3 wks Drop outs: NR CG1 (n = 17)– Information, Med + sham therapy: as IG + information on anatomy of cervical spine and patho-physiology, biomechanical problems and relaxation, related to practical problems + superficial massage, electric stimulation and slight relaxing traction; 3 hrs instruction, 3 tx/wk for 3 wks Drop outs: A = 8 CG2 (n = 23) – Information, Med + ManualMob: CG1 + mobilizing technique comprised of passive movements directed to actual mobile segments; as CG1 Drop outs: NR | Outcomes (describe instrument used): Pain: VAS Disability: NR Results: Immediate post tx: Pain: NR Disability: NR Short term, one wk post tx: pts with no pain: j2 (22%) vs. 2 (12%) vs. 11 (48% Intermediate: NR Long term: NA | Outcomes (describe instrument used): QoL/ well being: NR Increased mobility at the final tx: < 30 degrees: 16/23 vs. 11 vs. 17 vs. 8/23 > 30 degrees 7/23 vs. 6/17 vs. 15/23 Short term: NR Intermediate: NR Long term: NA Harms: pts with increased pain 5 (22%) vs. 2 (12%) vs. 1 (4%) In total, 16% of pts had some discomfort
Cassidy, J (1992)252 Country: Canada Quality score: 6/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: one session Fu duration (last assessment): immed. Post-tx N screened: NR N randomized: 100 N completed tx: 100 N attended last fu: 100 Inclusion: outPts suffering from unilateral mechanical NP with radiation into the trapezius muscle; pain aggravated by movement and local cervcial paraspinal tenderness Exclusion: NR | Mean age (SD/range): IG = 34.5 (13) vs. CG = 37.7 (12.5) yrs % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: History of NP, n = 78; Involved in car accident, n = 31; other minor trauma to neck, n = 28 Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S, 100% with radiating pain Duration of Pain, mean (SD/range): Mixed Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 52)– Manipulation: contacting third finger over articular pillar on painful side of neck at level of tenderness and passively rotating neck away from painful side as far as possible; then applying a high-velocity, low-amplitude thrust in the same direction; one session Drop outs: A = 0, B = 0 CG (n = 48) – Mobilization: application of muscle energy technique (Bourdillon Day) to hypertonic muscles responsible for restricting joint movement, pt instructed to push against manual resistance, localized force to involved levels; isometric contraction held for 5 sec, repeated 4 times with increasing rot or lateral flx of the neck; As IG Drop outs: A = 0, B = 0 | Outcomes: Pain: NRS (0-100) Results: Baseline: Pain: IG = 37.7 (25.9), CG = 31 (19.9) Immediate post tx: Pain: IG = 20.4 (21.2), CG = 20.5 (21) Short term: NR Intermediate: NR Long term: NA | Outcomes (describe instrument used): QoL/ well being: NR Range of motion (ROM): Immediate post tx flx: 61.0 (10.1) vs. 59.6 (14.0) ext: 59.9 (11.0) vs. 54.7 (14.6) gain scores for all ROM data was NSly differenet between groups Short term: NR Intermediate: NR Long term: NA Harms: No complications repported
Cleland JA (2007)256 Country: US Quality score: 7/13 Initial of reviewer: SG | Trial Design-RCT- Tx duration: NR Fu duration (last assessment): 3 mos N screened: 104 N randomized: 60 N completed tx: 60 N attended last fu: 60 Inclusion: Subjects aged 18-60 yrs with primary complaint of NP, and baseline NDI ≥ 10% Exclusion: Medical signs suggestive of non-musculoskeletal etiology, history of whiplash injury within 6 wks, spinal stenosis, CNS involvement, nerve root compression, previous cervico-thoracic surgery, or pending legal action | Mean age (SD/range): IG = 43.8 (11.5) vs. CG = 42.7 (13.9) yrs % of male: IG = 40%; CG = 50% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Mixed, IG = 55 (46) ds; CG = 56 (27.6) ds Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: N (%) NSAIDs: IG = 8 (27), CG = 16 (53); Pain meds IG = 2 (7), CG = 9 (30), muscle relaxant IG = 2 (7), CG = 3 (10) | Groups IG (n = 30) – Manipulation/ Mobilization with thrust: Pts received thrust M/M targeting the upper (T1 and T4) and middle (T5 and T8) thoracic spine; advice for EX; neck and head rot to both sides alternatively; advice for EX; neck and head rot to both sides alternatively; 3 min/session Drop outs: 0 CG (n = 30) – M/M without thrust: Prone position; 30-sec bout of grade 3-4 central posterior anterior-non thrust M/M at the T1 spinous process as described by Maitland et al; same technique applied to T2 and up to T6; advice for EX; neck and head rot to both sides alternatively; As IG Drop outs: 0 | Outcomes: Pain: Numeric Pain Rating Scale Disability: Neck Disability Index Results: Baseline: Pain: IG = 4.5 (2.1), CG = 5.3 (1.4) Disability: IG = 29.6 (12.6), CG = 33.5 (11.2) Short term: Pain: IG = 3.9 (2.2), CG = 2.7 (1.4) Disability: IG = 24.0 (13.4), CG = 18.0 (10.9) Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: Aggravation of symptoms (n = 10); Muscle spasm (n = 2); Neck stiffness (n = 2); Headache (n = 3); Radiating symptoms (n = 2)
Haas, M (2003)254 (phase 4 diagnostic trial) Country: US Quality score: 8/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: One session Fu duration (last assessment): 3 mos N screened: 108 N randomized: 104 N completed tx: 99 N attended last fu: 99 Inclusion: 18 yrs and older with min. pain level of 10 on 100mm VAS who had not received cervical manipulation in preceding 48 hrs Exclusion: cancer, blood dyscrasias, severe osteopenia, severe trauma or fracture, disc herniation or cervical radiculopathy, signs of vertebrobasilar insufficiency | Mean age (SD/range): IG = 42.2 (12.9) vs. CG = 42.9 (14.4) yrs % of male: IG = 41%, CG = 33% Racial composition: 92% White Work status: NR Other socio-demographics: NR Co morbidities: Prior episode of pain if acute: NA Prior CAM intervention: Prior surgery related to current complaint: NR | Region of pain: LBP, NP, thorax Cause of Pain: N-S Duration of Pain, mean (SD/range): Mixed, > 30: IG = 51%, CG = 63% Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 47)– Manipulation: supine high-velocity, low-amplitude manipulation of cervical spine targeted to individual cervical vertebrae according to whether cervical endplay restriction noted by examining clinician; 1 tx Drop outs: A = 0, B = 0 CG (n = 52) – Control: manipulation according to sham endplay findings generated by a computer algorithm; 1 tx Drop outs: A = 0, B = 0 | Outcomes: Pain: VAS for NP (100 mm)-11-pt NRS Disability: 100 mm VAS-11-pt NRS Results-Baseline: Pain: IG = 42.3 (16.5), CG = 40.4 (20.9) Disability: IG = 44.5 (17.7), CG = 43.9 (20.4) Immediate post tx: Pain: IG = 26.6 (20.2), CG = 24.7 (19.5) Disability: IG = 26 (20.2), CG = 24.4 (19.4) Short term: Pain: IG = 31.9 (20.3), CG = 28.7 (19.6) Disability: IG = 34.6 (18.5), CG = 30.2 (22.3) Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: immediate pain exacerbation for examination-based SM was no different from that for computer-generated indication for SM (odds ratio, 1.05; 95% CI, 0.36–3.04; P = 0.932).
Hurwitz, E (2002)251 Country: Korea Quality score: 7/13 Initial of reviewer: SG | Trial Design RCT- Tx duration: NR Fu duration (last assessment): 6 mos N screened: 1848 N randomized: 336 N completed tx: NR N attended last fu: NR Inclusion: 18-70 yrs belonging to a health maintenance organization, seeking care between Feb 9/98-June 30/00 presenting with NP, and not having received tx for NP in past mo Exclusion: NP due to fracture, tumor, infection, severe spondyloarthropathy, or other nonmechanical cause; progressive neurological deficit, myelopathy, herniated nucleus pulposus or severe incapacitating pain; | Mean age (SD/range): IG = 45.7 (11.8) vs. CG = 45.7 (12.2) yrs % of male: 31% Racial composition: 61.95% White Work status: 7.75% Unemployed Other socio-demographics: 65.6% Married Co morbidities: Head-ache, arm pain, arm numb Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: NR Duration of Pain, mean (SD/range): Unknown (mix) Severity of pain (Grading): NDI scores <5, >20 Current tx/ co-intervention common in all groups: Information about posture and body mechanics | Groups IG (n = 171) – Manipulation: at least one controlled dynamic thrust applied with high-velocity and low-amplitude force with minimal ext and rot directed at one or more restricted upper thoracic or cervical spine joint segments; with or without heat, with or without electrical muscle stimulation 4 wks Drop outs: NR CG (n = 165) – Mobilization: one or more low velocity, variable amplitude movements applied witin the passive ROM directed to 1 or ore restricted upper thoracic or cervical spine joint segments; with or without heat, with or without electrical muscle stimulation ; 4 wks Drop outs: NR | Outcomes: Pain: NRS Disability: NDI (0-50) Results-Baseline: Pain: IG = 6.4 (2.1), CG = 6.6 (2.1); IG = 4.7 (1.9), CG = 4.8 (1.9) Disability: IG = 13.1 (6.2), CG = 13.3 (6.3) Immediate post tx: Average pain: 0.97 ((95% CI: 0.77, 1.23) NDI: 1.05 (95% CI: 0.82, 1.35) Short term: Average pain: 0.93 (95% CI: 0.81, 1.17) NDI: 0.99 (95% CI: 0.79, 1.24) Intermediate: Average pain: 0.92 (95% CI: 0.74, 1.15) NDI: 0.85 (95% CI: 0.66, 1.08) Long term: NA | Outcomes: QoL/ well being: SF-36 physical function (all grps); SF-36 physical role (all grps) Results- mean: Baseline: 78.5 (20.57); 56.9 (38.57) Immediate post tx: Short term: NR Intermediate: NR Long term: NA Harms: pts in IG were more likely to experience transient AEs druign the initial 4 wks : 16% vs. 8.7%, p = 0.051
Kanlayanaphotporn, R (2009)258 Country: Thailand Quality score: 11/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: one session Fu duration (last assessment): immed. Post-tx N screened: 84 N randomized: 60 N completed tx: 60 N attended last fu: 60 Inclusion: mechanical NP, unilaterally distributed for at least 1-wk duration; symptoms primarily confined to area between superior nuchal line and tip of first thoracic spinous process and provoked by neck movements or by sustained neck postures; NP at rest > 20 on 100mm VAS Exclusion: contraindications to Mob; trauma/fracture of cervical spine; cervical spine surgery; SMwithin past mo; positive neurological examination | Mean age (SD/range): IG = 39.7 (10) vs. CG = 44.8 (13.6) yrs % of male: IG = 43.3%, CG = 36.7% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Mix, IG = 804.3 (149.4) ds; CG = 999.6 (182.5) ds Severity of pain (Grading): IG = 22.9 (10), CG = 26.5 (10) Current tx/ co-intervention common in all groups: | Groups IG (n = 30)– Ipsi-lateral uni-lateral postero-anterior Mob: over zygapophysial joint of cervical spine, on the side of the symptoms (ipsilateral); one tx Drop outs: A = 0, B = 0 CG (n = 30) – Random Mob: one of the following three Mob techniques that could be applied in a clinic as a placebo intervention: 1) central posteroanterior (PA) Mob; 2) ipsilateral unilateral PA; 3) contralateral unilateral PA pressure; one tx Drop outs: A = 0, B = 0 | Outcomes: Pain: 100 mm VAS as rest; 100 mm VAS at most painful movement Results: Baseline: Pain: IG = 47.4 (15.9), CG = 48.3 (22.2); IG = 59.5 (16.6), CG = 61.6 (23) Immediate post tx: Pain-mean change: IG = 10.8 (11.4), CG = 12.3 (12.5); IG = 16.7 (17.6), CG = 16.9 (16) Short term: NR Intermediate: NR Long term: NR | QoL/ well being: GPE-immediately post tx:Completely recovered: 2/30 vs. 2/30 Immediate post tx: Cervical ROM, changre from baseline (degree): Flextion: 1.9 (4.1) vs. -0.7 (4.5) Extension: 1.8 (6.3) vs. 0.8 (4.6) On most painful movement: 2.7 (5.5) vs. 1.4 (4.3) Short term: NR Intermediate: NR Long term: NA Harms: No AE as result of Mob was reported.
Martinez-Segura, R (2006)253 Country: Spain Quality score: 6/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: One session Fu duration (last assessment): Immed. Post-tx N screened: NR N randomized: 71 N completed tx: 71 N attended last fu: 71 Inclusion: age >/= 18 yrs; mechanical NP >/= 1 mo in duration referred by primary care physician Exclusion: contraindication to manipulation; fibromyalgia; whiplash injury history; history of cervical spine surgery; diagnosis of cervical radiculopathy or myelopathy; SM tx within one mo prior to study; positive result in ext-rot test | Mean age (SD/range): IG = 35 (10) vs. CG = 39 (10) yrs % of male: IG = 38.2%, CG = 35.1% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NA Prior CAM intervention: NR Prior surgery related to current complaint: None | Region of pain: NP Cause of Pain: Duration of Pain, mean (SD/range): Mixed, IG = 4 (3.4) wks, CG = 4.5 (4.6) wks Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 34)– Cervical HVLA: directed at dysfunctional level, with Pt supine with cervical spine in neutral position, HVLA thrust directed upwards, S cracking/popping sound accompanied all manipulations; 1 tx Drop outs: NR CG (n = 37) – Control (manual Mob): Pt supine with cervical spine in neutral position, held for 30 sec without additional tension and HVLA thrust, side of manual contact was randomized; 1 tx Drop outs: NR | Outcomes (describe instrument used): Pain: VAS NP at rest (0-100 cm) Results: Baseline: Pain: IG = 5.7 (1.5), CG = 5.5 (1.7) Immediate post tx: Pain: IG = 2.2 (1.5), CG = 5.1 (1.9) Improvement of pain (pre-post IG vs. pre-post CG): 3.5 (3.9, 3.1) vs. 0.4 (95% CI: 0.5, 0.2) Short term: NR Intermediate: NR Long term: NR | QoL/ well being: NR Improvement of ROM (pre-post IG vs. pre-post CG): Immediate post tx: flx 7.0 (95% CI: 9.0, 5.0) vs. 1.5 (95% CI: 2.4, 0.7) Short term: NR Intermediate: NR Long term: NR Harms: NR -tive association between the improvement in NP at rest & improvement on each ROM: flx (r = -0.6, P < .001), ext (r = -0.6, P P< .001) [less pain with better ROM]
Strunk, R (2007)257 Country: U.S Quality score: 6/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 2 wks Fu duration (last assessment): Post-tx N screened: 12 N randomized: 6 N completed tx: 6 N attended last fu: 5 Inclusion: Pts 20-65 yrs with primary complaint of mechanical NP for at least 4 wks. Pts who had secondary complaint of headache as long as their primary complaint was NP Exclusion: NP resulted from inflammatory joint disease, infection, tumor, fracture; comorbid disease that would contraindicate HVLA SM; currently receiving tx of NP by other health care providers; previous history of stroke, diagnosis of a bleeding disorder or currently undergoing anti-coagulation tx | Mean age (SD/range): IG = 42 (12) vs. CG = 54 (10) yrs % of male: IG = 0, CG = 16.7% Racial composition: 100% White/Non-Hispanic Work status: NR Other socio-demographics: 50% Married Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Mechanical Duration of Pain, mean (SD/range): Mixed, NR Severity of pain (Grading): ptw with grade 3 or 4 on Quebec Task Force classification system were excluded Current tx/ co-intervention common in all groups: NR | Groups IG (n = 3)– Cervical spine HVLA SM: pts received HVLA SM to C0 through C7 vertebral levels at the discretion of the doctor; 4 tx sessions over 2 wks Drop outs: 0 CG (n = 3) – Combined therapeutic approach: Pts received HVLA SM to T1 through T12 vertebral levels and the sacroiliac joints at discretion of doctor. Muscle energy technique administered according to Lewit procedure, 2 sets of 3 reps; Same as IG Drop outs: 1 | Outcomes: Median (range) Pain: VAS (0-100 mm) Disability: NDI (0-100) Results: Baseline: Pain: IG = 35.0 (12-34), CG = 29.0 (27-50) Disability: IG = 34.0 (12-34), CG = 24.0 (20-38) Immediate post tx: Pain: outcome by pts- data not shown Disability: outcome by pts- data not shown Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: Two indicated they experienced discomfort or an unpleasant reaction from study tx in post-tx response questionnaire
Vernon, H (1990)255 Country: Canada Quality score: 6/13 Initial of reviewer: SG | Trial Design- RCT Tx duration: One session Fu duration (last assessment): imm. Post-tx N screened: NR N randomized: 9 N completed tx: 9 N attended last fu: 9 Inclusion: Mechanical NP Exclusion: NR | Mean age (SD/range): 32.5 yrs % of male: 66.7% (total sample) Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Mixed, 2 wks-8 yrs [range] Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 5)– Rotational manipulation: high velocity, low amplitude thrust; one tx Drop outs: A = 0, B = 0 CG (n = 4) – Rotational Mob (sham): with gentle oscillations into the elastic barrier; one tx Drop outs: A = 0, B = 0 | Outcomes (describe instrument used): Pain: Pessure pain threshold by a PPT meter, kg/cm^2^ - avg for 4 tender pts Results: Baseline: Pain: IG = 3.375; CG = 2.45 Immediate post tx: Pain: IG = 4.95; CG = 2.525 Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Results- mean: Baseline: Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR Summary of results (if provided): mean age males: 27 yrs; mean age females 38 yrs

Table 2.15 Neck Pain - Manipulation & Mobilization - Unknown - Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other outcomes; Harms
Cilliers, K (1998)260 Country: South Africa Quality score: 3/13 Initial of reviewer: SG | Trial Design-RCT- Tx duration: 4 wks Fu duration (last assessment): 1 mos N screened: NR N randomized: 30 N completed tx: 30 N attended last fu: 30 Inclusion: 14 yrs of age or older with diagnosis of cervical facet syndrome; physically fit individuals with a cause of NP related to cervical facet syndrome Exclusion: organic cause of cervical pain or who had surgery on cervical spine; positive Wallenberg test | Mean age (SD/range): IG = 33 vs. CG = 29.3 yrs % of male: IG = 53.3%; CG = 26.6% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Facet joint syndrome Duration of Pain, mean (SD/range): Unknown, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: Pts were requested to not take any Med or other tx that may have influenced outcome of the study | IG (n = 15) – Transverse oscillatory rot segment adjustment: of the fixation into the restriction of motion; fixated segment determined by Kemp's test, motion palpation findings and local tenderness; only the most restricted fixation was adjusted; adjustment used a HVLA thrust using S contacts and line of drive; only cervical rotary adjustments were used; adjustment was preceded by 5 min of massage with oil; 8 tx over 4 wks Drop outs: NR CG (n = 15) – Transverse oscillatory rot and bottom segment adjustment: of the fixation into the restriction of motion, and the bottomsegment in the opposite direction; adjustment as IG, also preceded by 5 min of massage with oil; As IG Drop outs: NR | Outcomes: Pain: SF-MPQ Disability: NR No numeric data is reported-both grps improved sign. From baseline Results: Immediate post tx: Pain: NR Disability: NR Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR ROM: no numerica data is reported (IG vs. CG p< 0.05 for forward flx at mo fu) Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: bothe approaches to adjusting the cervical spine were effective in treating facet syndrome. IG2 was slightly more effective than IG1
Egwu (2008)261 Country: Nigeria Quality score: 1/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: Max.4 wks Fu duration (last assessment): post tx N screened: NR N randomized: 96 N completed tx: 96 N attended last fu: NR Inclusion: Diagnosis of cervical spondylosis referred for manipulative therapy; severe NP, unilaterally distributed relative to the midline of the neck; positive skin rolling test; no previous manual therapy, onset within 6 wks of entry to study; no history of vertebro-basilar insufficiency; 40-50 yrs old Exclusion: NR | Mean age (SD/range): IG1 = 43.9 (2.2), IG2 = 45.8 (3.23), IG3 = 42.7 (2.9), IG4 = 44.8 (3) yrs % of male: 100% Racial composition: 100% African Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NA Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Cervical Spondylosis Duration of Pain, mean (SD/range): Unknown, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = 24) – Posterior-anterior-unilateral pressure: NR; 3 tx/wk until cured – up to 4 wks Drop outs: 0 IG2 (n = 24) – Antero-posterior-unilateral pressure: NR; Same as IG1 Drop outs: 0 IG3 (n = 24) – Cervical oscillatory rot: NR; Same as IG1 Drop outs: 0 IG4 (n = 24) – Transverse oscillatory pressure: NR; Same as IG1 Drop outs: 0 | Outcomes: Pain: N of pts reporting 100% pain free immediately Immediate post tx: Pain: IG1 = 11 (46%), IG2 = 15 (63%), IG3 = 4 (17%), IG4 = 6 (25%) Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Short term: Number of pts returning for tx after 3 mos. IG12= 0; IG 3 3 (12%), IG4 2 (8%) Intermediate: NR Long term: NR Harms: none of the pts reported worse pain

Table 2.16 Neck Pain - Manipulation & Mobilization - Unknown - Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other outcomes; Harms
Cleland, J (2004)262 Abstract Country: US Quality score: 2/13 Initial of reviewer: SG | Trial Design RCT Tx duration: One session Fu duration (last assessment): NR N screened: 68 N randomized: 68 N completed tx: NR N attended last fu: NR Inclusion: 18-60 yrs of age with complain of mechanical NP Exclusion: NR | Mean age (SD/range): NR % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Unknown, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 34) – Thoracic spine manipulation: treating clinician performed a segmental evaluation of thoracic spine and then performed a thoracic spine manipulation to identified segmental restriction; one tx Drop outs: NR CG (n = 34) – Placebo: NR; one tx Drop outs: NR | Outcomes (describe instrument used): Pain: VAS (0 – 100) Results: Immediate post tx: Pain-mean change (reduction in pain): IG = -15.5 (95% CI: 11.8, 19.2), CG = -4.2 (95% CI: 1.9, 6.6), p < 0.001 Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Other: Results- mean: Baseline: NA Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR
Krauss, J (2008)264 Country: US Quality score: 9/13 Initial of reviewer: SG | Trial Design-RCT- Tx duration: One session Fu duration (last assessment): post tx N screened: 32 N randomized: 32 N completed tx: 32 N attended last fu: 32 Inclusion: 19 to 50 yrs with complaints of non-traumatic posterior mid-cervical pain of insidious onset in region of fourth to seventh cervical vertebral levels and aggravated with active cervical rot Exclusion: symptoms originating from thoracic spine, systemic disease or autoimmune disease affecting musculoskeletal system, positive radicular signs, myelopathy or previous surgery to cervical spine | Mean age (SD/range): IG = 35 (10.51) vs. CG = 34.2 (9.56) yrs % of male: IG = 14%; CG = 30% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Unknown, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | IG (n = 22) – Translatoric SM: using short straight-lined high and low velocity movements directed parallel to or at a right angle to spinal joint surfaces; Sally a bilateral translatoric facet joint traction manipulation to hypomobile UT intervertebral segments, a short passive linear movement perforemed in a dorsal direction perpendicular to plane of facet joints and parallel to plane or UT intervertebral disc joints at each level; one tx Drop outs: A = 0, B = 0 CG (n = 10) – No tx: no intervention to minimize N-S effects of sham tx but remained seated on tx table for approx. the same amount of time it would take for TSM to be performed; As IG Drop outs: A = 0, B = 0 | Outcomes: Pain: Faces pain scale to assess pain at end range of active cervical rot: right direction; left direction Results: Baseline: Pain: IG = 2.8 (2.7), CG = 2.8 (1.8); IG = 3.7 (2.7), CG = 2.5 (2.8) Immediate post tx change from baseline: right rot, 1.5 (2.88) vs. -1.0 (0.23) left rot: 0.69 (1.03) vs. 0.67 (1.2) Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: sign. Between group differences in riht rot only
Metcalfe, S (2006)266 Country: Canada Quality score: 4/13 Initial of reviewer: SG | Trial Design- RCT Tx duration: One session Fu duration (last assessment): NR N screened: NR N randomized: 67 N completed tx: 67 N attended last fu: 67 Inclusion: with NP or headaches Exclusion: non-cervicogenic NP or headaches, over 65 yrs had previous neck surgery, unable to achieve adequate ROM for strength test position (80° rot) or displayed radicular signs such as loss of reflexes, decreased sensation or fatigable weakness, if strength testing limited by pain or the result of strength testing was 66 pounds | Mean age (SD/range): 37 (11) yrs (total) % of male: 23.9% (total) Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Unknown Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 41) – Manipulation: low amplitude, high-velocity thrusts with a primary movement of side bending to dysfunctional segments in upper (c0-c2) and lower (c2-c7) cervical spine; lower cervical dysfunctional segments received linear thrust along tri-planar motion in direction of restricted movement; 1 tx Drop outs: A = 0, B = 0 CG (n = 26) – Manipulation: manipulation to dysfunctional segments of lower cervical spine only; 1 tx Drop outs: A = 0, B = 0 | Outcomes (describe instrument used): Pain: NA Disability: NA Results: Baseline: Pain: NA Disability: NA Immediate post tx: Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Mean strength (pounds): Immediate post tx: predicted weak: 19.6 (6.5) vs. 15.5 (6.4) predicted strong: 18.8 (5.4) vs. 15.8 (6.3) Short term: NR Intermediate: NR Long term: NR Harms: NR
Parkin-Smith, G (1998)265 Country: South Africa Quality score: 6/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 3 wks Fu duration (last assessment): Immed. Post-tx N screened: 30 N randomized: 30 N completed tx: 30 N attended last fu: 30 Inclusion: Mechanical NP without neurological or vascular deficit, unilateral or bilateral, possible discomfort with joint challenge/pressure, restriction of movement of at least one motion segment identified by motion palpation, between 16-60 yrs old, exhibit a negative Wallenberg's test Exclusion: Radiculopathy, contraindications to SM, history of cardiovascular disease, hypertension or dizziness, received manual therapy for at least 2 wks prior to study | Mean age (SD/range): IG = 33.8 vs. CG = 37 yrs % of male: IG = 54%, CG = 71% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Unknown, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: no Med was allowed during the study | Groups IG (n = 13) – Cervical SM: most fixated segment(s) were manipulated (no more than 2). Chiropractic adjustments were applied; S manipulative techniques were selected and given in the form of cervical breaks, combination movements, crossed bilateral ransvers pisiform, and anterior thoracic techniques. If required, pts received brief (no more than 20-30 min) of non-therapeutic pre-manipulative soft-tissue massage of cervical spine for muscle spasm; 2 tx/wk for 3 wks Drop outs: NR CG (n = 17) – Cervical and upper thoracic SM: most fixated cervical and thoracic segments were manipulated, not extending below T7; As IG Drop outs: NR | Outcomes: Pain: NPRS-101 (0-100) Disability: CMCC NDI (0-100) Results: Baseline: Pain: IG = 33.89 (12.47), CG = 33 (13.99) Disability: IG = 18.24 (9.66), CG = 17.64 (8.17) Immediate post tx: Pain: IG = 17.17 (18.41), CG = 13.18 (10.56) Disability: IG = 6.89 (8.17), CG = 4.71 (5.74) Short term: NR Intermediate: NR Long term: NA | Outcomes (describe instrument used): QoL/ well being: NR ROM, mean change from baseline: Immediate post tx: Flexion: 3.71 (3.9) vs. 1.4 (1.8) Extension: 2.7 (3.9) vs. 1.7 (2.8) Right lateral flx: 2.0 (3.2) vs. 2.6 (2.6) Right rot: 2.6 (3.2) vs. 3.5 (3.3) Left rot: 1.8 (3.6) vs. 3.6 (5.2) Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: two tx were not different
Van Schalkwyk, R (2000)263 Country: South Africa Quality score: 1/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 4 wks Fu duration (last assessment): 3 mos N screened: NR N randomized: 30 N completed tx: 30 N attended last fu: 30 Inclusion: over 15 yrs of age with mechanical NP with lateral flx fixations in cervical spine, literate Exclusion: pathologic condition or disease; contraindications to manipulation, no form of analgesic or anti-inflammatory before or during tx | Mean age (SD/range): IG = 31.7 vs. CG = 27.7 yrs % of male: IG = 80%, CG = 53.3% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Unknown, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 15)– Manipulation on ipsilateral side: supine cervical rotary break manipulation with contact taken on ipsilateral side of lateral flx fixation; 10 tx over 4 wks Drop outs: NR CG (n = 15) – Manipulation on contralateral side: supine lateral break manipulation on contralateral side of lateral flx fixation; As IG Drop outs: NR | Outcomes: Pain: NPRS-level of pain intensity; SF-McGill-quality of pain Disability: CMCC (CANadian Memorial Chiropractic Colledge) NDI Results- Immediate post tx: Pain: IG = 9.4 (5.47), CG = 17.54 (12.47);IG = 4.27 (8.17), CG = 7.48 (13.47) Disability: IG = 6 (5.74), CG = 6.13 (18.41) Short term: Pain: IG = 11.83 (11.8), CG = 18.52 (14); IG = 6.18 (5.8), CG = 9.08 (10.7) Disability: IG = 6 (6.8), CG = 6.13 (8) Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NA Cervical ROM Immediate post tx, Flexion: 60.8 (12.9) vs. 60.9 (11.67) Extension: 53.4 (13.6) vs. 54.8 (12.2) Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: both txs were effective but there was no sign. Difference between the grps

Table 2.17 Neck Pain- Spinal Mobilization- Acute – Specific Pain – No studies

Table 2.18 Neck Pain- Spinal Mobilization- Acute – Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other outcomes; Harms
Buchmann, J (2005)236 Country: Germany Quality score: 7/13 Initial of reviewer: SG | Trial Design-RCT- Tx duration: NR Fu duration (last assessment): 24 hrs post last tx N screened: 60 N randomized: 26 N completed tx: 24 N attended last fu: NR Inclusion: 18-80 yrs, manually diagnosed dysfunction of one or both of the segments occiput/cervical 1 and cervical 1/cervical 2 Exclusion: previous surgery of cervical spinal column, arthrosis of cervical spinal column, spondylolisthesis, fracture, inflammation, previous disk herniations or cervical spinal column, any kind of cancer or planned surgery in throat | Mean age (SD/range): IG = 44 (22), IG2 = 46 (14), CG = 49 (7) yrs % of male: IG = 60%; IG2 = 62%; CG = 50% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: NR Duration of Pain, mean (SD/range): Acute/Sub-acute NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = 10) – SM: thrusting force on lateral aspects of occiput or C1 exerted for < 200 msec pre/post anesthesia; NR Drop outs: A = 0, B = 2 IG2 (n = 8) – Post-isometric relaxation): applied to hypertonic muscle - isometric contraction by pts against manual resistance for 10 sec then stransverse oscillatory rotped and repeated after at least 20 sec rest;pre/post anesthesia NR Drop outs: See IG1 CG (n = 8) – Placebo: Laying palms of clinician on sides of pt's neck without any side-different pressure or without having pt under tension; pre/post anesthesia NR Drop outs: See IG1 | Outcomes: Disability: N of found dysfunctions in motion segments O/C1 and C1/C2- no numerical data is reported (only p values) Results: Baseline: Disability: IG1 = 21, IG2 = 15, CG = 13 Immediate post tx: Disability: --- Short term: NR Intermediate: NR Long term: NA | Outcomes: QoL/ well being: NR Short term: NR Intermediate: NR Long term: NA Harms: 2 WDAE in IG1- complication arising from a surgical operation Summary: sig effect of IG1&2 vs. placebo, in restoring function (p< 0.01) In anesthesia: IG1 vs. placebo, p < 0.01. No sig difference between IG1 & 2 (P = 0.137). The tx effect postnarcotically was further sign in IG1 vs. placebo only (P = 0.01)

Table 2.19 Neck Pain - Massage - Acute - Specific Pain – No studies

Table 2.20 Neck Pain - Massage - Acute - Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other outcomes; Harms
Blikstad, A (2007)267 Country: England Quality score: 10/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: One session Fu duration (last assessment): post tx N screened: 45 N randomized: 45 N completed tx: NR N attended last fu: NR Inclusion: Between 18-55 yrs. N-S unilateral or bilateral NP of at least 4 wks, no longer than 12 wks and at least 4 on an 11-pt (NRS), an upper trapezius TP (TP) and decreased cervical lateral flx to the opposite side of the active upper trapezius TP. NP could extend to shoulder region and upper arms Exclusion: Specific NP; blood coagulation disorders, currently taking anticoagulants; long-term steroid use | Mean age (SD/range): IG1 = 23.9 (3.925), IG2 = 22.6 (2.384), CG = 24.9 (5.44) yrs % of male: IG1 = 27, IG2 = 60, CG = 47 Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP and upper trapezius TPs Cause of Pain: N-S Duration of Pain, mean (SD/range): Sub-acute, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = 15)– Activator TP tx (ATPT): An force to TP = 170 Newton : One session, 10 thrusts at 1 thrust/sec Drop outs: NR IG2 (n = 15) – Myofascial band tx (MBT): Firm thumb pressure in a slow stroking motion from the lateral shoulder to the mastoid process along the upper trapezius muscle and through the active TP; One 1 min session Drop outs: NR CG (n = 15) – Sham Ultrasound (SUS): If subject felt any sensation of heat or pain, machine was turned down- same area as IG; One 2 min session Drop outs: NR | Outcomes: Pain: NRS (0-10); PPT (kg/cm^2^) Disability: CROM Results: Baseline: Pain: IG1 = 4.6 (0.6325), IG2 = 4.6 (0.5071), CG = 4.7 (0.9612); IG1 = 3.4 (1.803), IG2 = 3.2 (0.8367), CG = 3.8 (1.71) Disability: NR Immediate post tx: Pain: NR Disability: NR Short term: NR Intermediate: NR Long term: NA | Outcomes: QoL/ well being: NR Number of subjects improved based on reduced pain: Immediate post tx: 8 (53.3%) vs. 2 (13.3%) vs. 2 (13.3%) Based on right lateral cervical flx: 6 (40%) vs. 5 (33.3%) vs. 6 (40%) Short term: NR Intermediate: NR Long term: NA Harms: NR

Table 2.21 Neck Pain - Massage - Chronic- Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other outcomes; Harms
Cen, S (2003)271 Country: Germany Quality score: 4/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 6 wks Fu duration (last assessment): Post-tx N screened: 31 N randomized: 31 N completed tx: 28 N attended last fu: 28 Inclusion: NP and loss in ROM, for more than 1 yr, noticeably daily NP and tightness, neck muscle pain and tightness associated with a mechanical disorder of the cervical spine (such as whiplash/trauma, chronic use, disc degeneration, post-herniated nucleus pulpous), no regular therapeutic tx (more than once/wk) in previous 3 mo for NP Exclusion: NR | Mean age (SD/range): IG1 = 47 (11), IG2 = 48 (13), CG = 51 (7) yrs % of male: IG1 = 20, IG2 = 30, CG = 27.3 Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Region of pain: NP Cause of Pain: Trauma (35.8%) Chronic use/stress (51.2%); Post-herniated nucleus pulposus (10%); Spinal malformation sue to arthritis (3.0%); Spinal malformation due to post-polio syndrome (3.3%) Duration of Pain, mean (SD/range): Chronic, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = 10)– Traditional Chinese Massage (TCTM): one-finger meditation massage used to search and treat any perceived abnormal soft tissue sites; 30 min/tx, 3 tx/wk, 6 wks Drop outs: A = 1 IG2 (n = 10)– Exercise program: Home-based, self-administrated. 2 steps: 1) application of moist heat on neck area followed by S stretching EX. Daily EX program included head tilt, trapezius stretch, neck flx, shoulder rolls, and neck rolls; moist heat for 10 min, stretching for 10 min Drop outs: A = 2 (personal family problems) CG (n = 11) – No tx: NA; NA Drop outs: NR | Outcomes: Pain: Northwick Park NP Results-Baseline: Pain: IG1 = 32.46 (8.59), IG2 = 27.81 (11.9), CG = 31.51 (12.11) Immediate post tx: Pain: IG1 = 13.24 (11.88), IG2 = 20.23 (12.06), CG = 35.64 (12.54) Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: NR Summary: Exercise plus TCTM appeared equally effective as TCTM alone but better than just EX only, suggesting that TCTM may provide the initial major contribution to the tx effect. Also, improvements in ROM for TCTM group seemed more consistent than EX group
Irnich D (2001)269,270 Country: Germany Quality score: 4/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 3 wks Fu duration (last assessment): 6 mos N screened: 182 N randomized: 177 N completed tx: 177 N attended last fu: 165 Inclusion: Pts with chronic NP (>1 mo) and painful restriction of cervical spine mobility who had not received any Tx in the two wks before the study Exclusion: Pts with dislocation, had surgery, fracture, neurological deficits, systemic disorders, or Tx contraindications | Mean age (SD/range): IG1 = 52.3 (13.3), IG2 = 52.7 (11.5), CG = 52.2 (13.2) yrs % of male: 33.97% total Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: (n) whiplash = 56; MPS = 129 Prior CAM intervention: NR Prior surgery related to current complaint: None | Region of pain: NP Cause of Pain: Myofascial pain and whiplash Duration of Pain, mean (SD/range): Chronic, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: None | Groups IG1 (n = 56)– Acu: according to traditional Chinese medicine rules, local MTPs treated with dry needling to elicit local twitch, common points S13, UB10, UB60, Liv3, GB20, GB34, TE5, and the ear point cervical spine; 5 tx, 3 wks Drop outs: D = 7 IG2 (n = 60)– Massage: Conventional Western massage (effleurage, petrissage, friction, tapotement, and vibration), SM not performed; Same as IG1 Drop outs: D = 1 CG (n = 61) – Sham-laser: Inactivated laser pen, every point treated for 2 min at 0.5-1 cm distance from the skin; Same as IG1 Drop outs: D = 4 | Outcomes: Pain: VAS; PPT Results-Baseline: Pain: IG1 = 54.15 (21.91), IG2 = 54.71 (23.46), CG = 57.15 (26.71); IG1 = 1.07 (0.57), IG2 = 1.07 (0.58), CG = 1.05 (0.57) Immediate post tx: Pain-mean change: IG1 = 25.3 (22.6), IG2 = 12.7 (29.5), CG = 19.2 (26.5); IG1 = 0.06 (0.58), IG2 = 0.04 (0.5), CG = -0.03 (0.51) Short term: --- Intermediate: IG1 = 17.4 (29.7), IG2 = 14.4 (31.9), CG = 17.4 (26.4); IG1 = 0.19 (0.77), IG2 = 0.50 (0.59), CG = 0.03 (0.62) Long term: NR | Outcomes: QoL/ well being: SF-36: Physical role; Pain Index Results- mean: Immediate post tx: Short term: (P values)IG1 vs. IG2 = 0.797, IG1 vs. CG= 0.498; IG1 vs. IG2 = 0.843, IG1 vs. CG = 0.989 Intermediate: IG1 vs. IG2 = 0.865, IG1 vs. CG = 0.825; IG1 vs. IG2 = 0.971, IG1 vs. CG = 0.87 Long term: NR Harms: Mild reactions n = 17 (33%) in IG1, vs. 4 (7%) in IG2, and 12 (21 %) in CG, no SAEs observed.
Yagci, N (2004)268 Country: Turkey Quality score: 2/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 2-5 ds Fu duration (last assessment): post tx N screened: 40 N randomized: 40 N completed tx: NR N attended last fu: NR Inclusion: Diagnosis of MPS (MPS) with duration of symptoms of at least 6 mos Exclusion: NR | Mean age (SD/range): IG = 30.7, CG = 31, SD NR % of male: IG = 35%, CG = 15% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: LBP Cause of Pain: NR Duration of Pain, mean (SD/range): chronic, NR Severity of pain (Grading): VAS Current tx/ co-intervention common in all groups: NR | Groups IG (n = 20)– Vapo coolant spray + stretch technique: Ethylchloride spray for 4-5 s to each muscle, from 30 cm distance and 45 degree angle; spray stretch technique + active EXs (same for both grps), 10 reps, 3 tx/d- 6 sessions in total Drop outs: NR CG (n = 20) – Connective tissue massage: starts from sacral region and terminated to shoulder and cervical regions; CT massage + active EXs(same for both grps), 10 reps, 3 tx/d- 6 sessions in total Drop outs: NR | Outcomes: Pain: VAS(0-10); Pain threshold; Pain tolerance Disability: NR Results: Immediate post tx: Pain (VAS): IG = 2.88 (1.5), CG = 2.6 (1.73); PPT IG = 37.05 (4.52), CG = 21.7 (8.42); Pain tolerance IG = 94.85 (5.56), CG = 81.75 (5.65) Disability: NR | Outcomes QoL/ well being: NA ROM Immediate post tx:flx 42.2 (7.18) vs. 46.4 (5.7) Extension: 52.2 (8.4) vs. 50.4 (5.9) Short term: NR Intermediate: NR Long term: NR Harms: NR Summary of results (if provided): Spray Stretch technique seemed to be most effective on trigger points as they required less time (only 6 sessions vs 15 for CMT)

Table 2.22 Neck Pain - Massage - Chronic - Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other outcomes; Harms
Cen, S (2009)273 Country: US Quality score: 8/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 10 wks? Fu duration (last assessment): 6 mos N screened: 222 N randomized: 64 N completed tx: 59 N attended last fu: NR Inclusion: group health enrollees between 20 - 64 yrs who had received primary care for NP at least 3 mo prior Exclusion: NP likely due to a non-mechanical cause; complex NP or NP potentially inappropriate for massage, prior neck surgery, MVA in past 3 mo; unstable serious medical or psychiatric conditions or demetia; minimal NP or NP lasting less than 12 wks; currently receiving other tx for NP apart from Meds; had used massage for NP within the last yr | Mean age (SD/range): IG = 47.4 (12.3) vs. CG = 46.4 (11.3) yrs % of male: 31.2 Racial composition: Majority White (87.1 vs. 81.3%) Work status: Employed: 84.4% Other socio-demographics: Family income > $35 K: 78.7% Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic, (pts with > 1 yr: 80.6%) Severity of pain (Grading): rating of < 3 on 0 - 10 point bothersome scale Current tx/ co-intervention common in all groups: all pts were advised on stretching and were allowed to take Med for NP: 56.3 vs. 62.5%; NSAIDs: 456.9 vs. 53.1%; narcotic analgesics: 6.3% | Groups IG1 (n = 32)– Massage: median of 7 techniques with a range of 4 to 15 per visit, most common technique: kneading, clinical gliding; At least 1 tx, (1-10 tx) Drop outs: 1 CG (n = 32) – Self-care book: NR; NA Drop outs: 4 | Outcomes: Pain: symptom bothersome: numerical 0-10 scales Disability: NDI Results-Baseline: Pain: IG = 4.8 (2.3), CG = 4.9 (1.8) Disability: NR Immediate post tx: Pain: improvement (% of pts): 55% vs. 25%, RR=2.2; 95% CI, 1.04, 4.2) Disability: improvement (% of pts): 39% vs. 14% (RR=2.7, 95% CI: 0.99, 7.5) Short term: NR Intermediate: Pain: RR = 1.1 (95% CI: 0.6, 2.0) NDI: RR = 1.8 (95% CI: 0.97, 3.5) Long term: NR | Outcomes: Global rating of improvement (%) Better or much better: at 4 wks: 58% vs. 7% At 10 wks: 55% vs. 25% At 6 mos: 43% vs. 25% Medication usage, (similar at baseline), did not change in the IG but increased by 14% in CG at 6 monhts Long term: NR Harms: IG: n = 9 with mild AEs; n = 5 with discomfort or pain during massage tx; n = 3 increased soreness after tx; n = 1 migraines and nausea one d after tx; one pt withdrew from tx; no SAEs observed
Zaproudina, N (2007)272 Country: Finland Quality score: /13 Initial of reviewer: SG | Trial Design RCT Tx duration: Not clear, 5-10 wks? Fu duration (last assessment): 1 yr N screened: NR N randomized: 102 N completed tx: 102 N attended last fu: NR Inclusion: Pts with chronic N-S NP aged 28-50 yrs Exclusion: Previous neck surgery; current nerve root entrapment; spinal cord compression; severe neurologic, metabolic, psychiatric or CVD diseases; any therapy or sick leave previous mo | Mean age (SD/range): IG1 = 41.2 (5.7), IG2 = 40.9 (5.9), CG = 42.4 (5.9) yrs % of male: IG1 = 31, IG2 = 38.2, CG = 33.3 Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: None | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Chronic, IG1 = 11.7 (6.2), IG2 = 10.6 (6.5), CG = 11.2 (7.3) yrs Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: None | Groups IG1 (n = 35)– Traditional bone setting: 5 sessions (each 1.5 hrs) per pt provided with 1-2 wk intervals Drop outs: D = 0 IG2 (n = 34)– Physiotherapy: Included massage, therapeutic stretching, and EX therapy; 5 sessions; session duration: 45 min Drop outs: D = 1 CG (n = 33) – Massage: 5 sessions (each 1 hr) per pt Drop outs: D = 2 | Outcomes: Pain: VAS (100 mm) Disability: NDI (0-100) Results-Baseline: Pain: IG1 = 49.5 (21.3), IG2 = 46.8 (19.8), CG = 46.6 (22.2) Disability: IG1 = 24.11 (8.2), IG2 = 27.41 (8.8), CG = 26.0 (10.9) Immediate post tx: Pain: IG1 = 17.9 (18), IG2 = 29.6 (23), CG = 25.4 (22) Disability: IG1 = 11.7 (9), IG2 = 18.4 (10), CG = 15.3 (10) Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Numer of sick-leave ds: 0.61 /peroperson in IG1, 2.6 in IG2, and 3.9 in CG Decrease in use of painkillers: 65.7% vs. 50.0% vs. 56.2% Immediate post tx: NA Short term: NR Intermediate: NR Long term: NR Harms: None of the pts in IG1 had any negative effects.

Table 2.23 Neck Pain - Massage - Mixed - Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other outcomes; Harms
Fernandez-de-las-Penas (2005)275 Country: Spain Quality score: 7/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: NR Fu duration (last assessment): Post-tx N screened: 40 N randomized: 40 N completed tx: NR N attended last fu: NR Inclusion: At least 18 yrs old, with mechanical NP for at least 2 wks, diagnosed with MTPs either latent or active in the upper trapezius muscle. Mech NP defined as: generalized neck and/or shoulder paint with mechanical characteristics Exclusion: diagnosis of fibromyalgia syndrome; history of whiplash injury, cervical spine surgery; diagnosis of radiculopathy or myelopathy determined by their physician; having undergone myofascial pain therapy within the past mo before study | Mean age (SD/range): IG1 = 27.7 (5.5), IG2 = 29.7 (6.2) yrs % of male: IG1 = 40, IG2 = 45 Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP & Upper Trapezius Cause of Pain: Mechanical Duration of Pain, mean (SD/range): Mixed, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = 20)– Ischemic compression technique: Patient lays supine with cervical spine in neutral position. Therapist applies gradually increasing pressure to MTP until sensation of pressure becomes pressure and pain. Pressure maintained until discomfort and/or pain eased by around 50%, then pressure was increased until discomfort appeared again. Repeated for 90sec ; NR Drop outs: NR IG2 (n = 20)–Transverse friction massage: Applied with forefinger and reinforced with middle finger. Executed with relaxed muscle applied for 3 min. Frictions applied slowly with a pressure slightly painful. Approx at PPT level of each pt; NR Drop outs: NR | Outcomes: Pain: PPT; VAS (2.5 kg/cm^2^) Disability: NA Results: Baseline: Pain: IG = 1.8 (0.5), CG = 2 (0.4); IG = 4.6 (1.2), CG = 4.9 (1.5) Immediate post tx: Pain: IG = 2.2 (0.6), CG = 2.35 (0.4); IG = 3.8 (0.9), CG = 4.2 (0.09) Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR
Lin, M (2004)220 Country: China Quality score: 3/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 3 mos Fu duration (last assessment): post tx N screened: 100 N randomized: 100 N completed tx: NR N attended last fu: NR Inclusion: Cervical spondylopathy of nerve root type, aged 25-76 Exclusion: NR | Mean age (SD/range): IG = 46(8.5) , CG = NR % of male: IG= 65% CG= NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP and vertebrae Cause of Pain: NR Duration of Pain, mean (SD/range): Acute to chronic(15 ds – 32 yrs) Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 50)– Needle scalpel combined with massage therapy; every 7 ds, tx course was 3 times, each course 7 times Drop outs: NR CG (n = 50) – Simple massage therapy once a d, and 7 times. Three courses were performed continuously and interval of each course was 3 ds Drop outs: NR | Outcomes (describe instrument used): Pain: NA Disability: NA Results: Baseline: NA Pain: Disability: Immediate post tx: NA Pain: Disability: Short term: NR Intermediate: NR Long term: NR | QoL/ well being: NR Cure effect measured by% of pts who were completely cured Immediate post tx: 16(32%) vs. 10(20%) Effective rate: 98% (49/50) vs. 82% (41/50), p < 0.05 Short term: NR Intermediate: NR Long term: NR Harms: NR
Xi-zhen (2005)274 Country: China Quality score: 1/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 5-10 ds Fu duration (last assessment): Post-tx N screened: NR N randomized: 52 N completed tx: 52 N attended last fu: 52 Inclusion: diagnosis of cervical spondylopathy owing to first attack or repeated attacks; meeting criteria for non-operation therapy Exclusion: operation owing for spondylopathy; mental disease; liver and kidney disease, blood disease, carcinoma; respiratory system and cerebrovascular or cardiovascular system complications; autoimmune disease or the weakest health Pts; equipped with cardiac pacemaker and prosthetic value; pregnancy or breast feeding | Mean age (SD/range): NR % of male: 55.8 Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Cervical spondylopathy Duration of Pain, mean (SD/range): Mixed, 5 ds-8 yrs Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 26)– Traction and Massage: of cervical vertebrae: traction by 5% of body mass increased by 2.5-5.0 N every 2-3 times; massage was given in prone position with methods consisting of grasping, pressing, pushing, kneading, rolling, tapping and traction and counter traction etc; Traction: 30 min/tx, Massage: 8-10 min/tx, 5 tx/course, 1-2 courses, Drop outs: A = 0, B = 0 CG (n = 26) – Traction only: traction of cervical vertebrae and massage: traction was done by special band on traction shelf with Pt sitting, first traction force was given by 5% of body mass and then tractio force increased by 2.5-5.0 N every 2-3 times; As IG Drop outs: A = 0, B = 0 | Outcomes: Pain: Cervical Spondylopathy Treatment Effect Rating Scale-3 items Disability: NA Results: Baseline: NA Pain: IG = 8.132 (2.534), CG = 8.304 (2.71) Immediate post tx: Pain: IG = 16.431 (3.212), CG = 13.147 (3.036) Short term: NR Intermediate: NR Long term: NR | Outcomes: QoL/ well being: NR Effect rate, post tx (obviousely effective): 80.8% vs. 46.2% Results- mean: Baseline: NA Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR
Zhang, B (2005)228 Country: China Quality score: 0/13 Initial of reviewer: SG | Trial Design RCT Tx duration: 3 wks Fu duration (last assessment): 3 mos N screened: NR N randomized: 96 N completed tx: NR N attended last fu: NR Inclusion: NR (appears to include pts with cervical spondylosis only) Exclusion: NR | Mean age (SD/range): NR % of male: IG = 65.63%, CG = 56.25% Racial composition: Asian Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: 4? Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Cervical spondylosis Duration of Pain, mean (SD/range): Mixed, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 64) – Acupuncture + Massage / Manipulation:. Acupoint injection - Fengchi (GB 20), bilaterally, Ashi points (spot of tenderness or node), 1 to 2; Drugs: VB12500ug (1 ml), Danshen injection 2 mL (1 g/mg), 2 % lidocaine 1 ml. The above drugs were drawn into a one- off 5ml syringe. the doctor inserted the needle into the points and injected the same amount of drugs into each point. If there was no bleeding, the needle was withdrawn with the arrival of qi; 3 tx/wk for 3 wks Drop outs: NR CG (n = 32) – Massage: As IG; Same as IG Drop outs: NR | Outcomes (describe instrument used): Pain: NA Disability: NA Results: Baseline: Pain: NA Disability: NA Immediate post tx: Pain: NA Disability: NA Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Cure rate: Immediate post tx: 81.25% vs. 56.25, p < 0.05 Total effective rate were similar in two grps Short term: NR Intermediate: NR Long term: NR Harms: NR

Table 2.24 Neck Pain - Massage - Mixed - Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other outcomes; Harms
Gemmell, H (2007)276 Country: England Quality score: 9/13 Initial of reviewer: SG | Trial Design RCT Tx duration: One session Fu duration (last assessment): post-tx N screened: 55 N randomized: 45 N completed tx: 45 N attended last fu: 45 Inclusion: Between ages 18 and 55 with N-S NP of at least 30 mm on a VAS, and upper trapezius TP and decreased cervical lateral flx to the opposite side of the active upper trapezius TP Exclusion: Those taking anticoagulants or using long-term corticosteroid therapy, and those with S causes for their NP | Mean age (SD/range): (median) IG1 = 24, IG2 = 24, CG = 23 yrs % of male: NR Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP and Upper Trapezius TPs Cause of Pain: N-S Duration of Pain, mean (SD/range): Mixed, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = 15)– Ischemic compression (IC): Sustained deep pressure with the thumb to the upper trapezius trigger pt (TP).; one tx session, sustained deep pressure for 30 s-1min Drop outs: NR IG2 (n = 15)– Trigger Point Pressure Release (TPPR): Non painful slowly increasing/ maintaining pressure with thumb over TP until tissue resistance barrier felt. Process repeated until no TP tension/tenderness of 90s had elapsed; one session Drop outs: NR CG (n = 15) – Sham Ultrasound (SUS): Ultrasound lotion applied over TP and ultrasound head was moved slowly over the upper trapezius muscle; one 2 min session, Drop outs: NR | Outcomes: Pain: VAS (0-100); PPT (kg/cm^2^) Results: Baseline: Pain: IG1 = 41.3 (43.6), IG2 = 43.6 (8.8), CG = 38.1 (8.8); IG1 = 3.39 (1.16), IG2 = 2.8 (1.2), CG = 2.6 (0.83) Immediate post tx: Pain: IG1 = 22.93 (12.76), IG2 = 27.13 (16.4), CG = 22.67 (8.21); IG1 = 4.45 (1.69), IG2 = 3.77 (1.76), CG = 3.37 (1.62) Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR
Hemmila, H (2005)277 Country: Finland Quality score: 5/13 Initial of reviewer: SG | Trial Design-RCT Tx duration: 5 wks Fu duration (last assessment): 1 yr N screened: 59 N randomized: 42 N completed tx: 38-40 N attended last fu: 38 Inclusion: 18-64 yrs; diagnosis of tension neck syndrome with N-S pain between the shoulders and occiput for at least one mo Exclusion: any tx during preceding mo; any contraindication to manual therapy; NP < 25/100mm on VAS | Mean age (SD/range): IG = 47.5 (8.5) vs. CG = 44.9 (9.7) yrs % of male: IG = 40.1 %, CG = 20% Racial composition: NR Work status: NR Other socio-demographics: Used folk medicine: 66.5% Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Unknown (mix), IG = 4.3 (4.7) yrs, CG = 8.4 (6.8) yrs Severity of pain (Grading): ≥ 25 mm Current tx/ co-intervention common in all groups: NR | Groups IG (n = 22)– Bone setting: pt asked to bend neck forward and backward while healer presses thumbs on both side of net distal vertebrae OR make careful rotating bending movements of pt’s head with one hand while pt’s neck is stabilized by other hand, some soft tissue massage; Five 30 min sessions over 5 wks Drop outs: E = 4 CG (n = 20) – Control: neither offered nor denied any therapy by the study protocol; as requested by the pt Drop outs: See IG | Outcomes: Pain: Million scale (0-100 mm); Pain drawings (Pain area; Numbness area) Results- Immediate post tx: Pain-mean change: IG = 18.5, CG = 4; IG = 3.5, CG = 2.1; IG = 0.8, CG = 1.2 Short term-mean change: IG = 21.2, CG = 6.2; IG = 4.9, CG = 1.5; IG = 1.3, CG = 1.5 Intermediate-mean change: IG = 22.9, CG = 5.4; IG = 2.9, CG = -0.4; IG = 1.6, CG = 0.5 Long term-mean change: IG = 14.2, CG = 5.5; IG = 4.4, CG = -1.3; IG = 1.5, CG = 1.9 | Outcomes: QoL/ well being: NR Medication use, and sick leaves Immediate post tx: NR Short term: NR Intermediate: NR Long term: NA Pain Med The mean annual N of doses: IG= 63 (146) vs. CG= 188 (332) Sick leaves prescribed for NP :IG= 3 vs. CG = 5 for mean of 4.5 (20.0) and 16.9 (53.0) ds Harms: NR

Table 2.25 Neck Pain - Massage - Unknown - Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other outcomes; Harms
Fryer (2005)280,281 Country: Australia Quality score: 5/13 Initial of reviewer: SG | Trial Design RCT Tx duration: One session Fu duration (last assessment): post tx N screened: NR N randomized: 37 N completed tx: NR N attended last fu: NR Inclusion: Presence of latent MTPs in the upper trapezius muscle Exclusion: Generalized primary fibromyalgia syndrome, taken analgesic Med in the past 24 hours, had no identifyable myofascial MTPs in the upper trapezius muscle | Mean age (SD/range): 23.1 (3.2) yrs % of male: 32.4 Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Myofascial TP Duration of Pain, mean (SD/range): Unknown, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = 20)– Massage: Myofascial manual pressure release; one tx Drop outs: NR CG (n = 17) – Sham myofascial release: extremely light pressure; same as IG Drop outs: NR | Outcomes: Pain: PPT Results: Immediate post tx: Pain-mean change: IG = -2.05 (1.7), CG = 0.083 (1.7) Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR
Hanten, W (1997)278 Country: US Quality score: 5/13 Initial of reviewer: SG | Trial Design RCT Tx duration: One session Fu duration (last assessment): Post-tx N screened: NR N randomized: 60 N completed tx: 60 N attended last fu: 60 Inclusion: Pts with one or more active or latent cervical and or scapular TPs Exclusion: Known orthopedic cardiovascular or neurological conditions. Not received clinical tx for the TP | Mean age (SD/range): 29.9 (9.2) yrs % of male: 30 Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Myofascial TP Duration of Pain, mean (SD/range): Unknown, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = 20)– Occipital Release: traction; One tx Drop outs: 0 IG2 (n = 20)– Retraction/Retraction-Extension: head traction and retraction/ext EXs; Same as IG1 Drop outs: 0 CG (n = 20) – No Tx: 5 min sitting upright; Same as IG1 Drop outs: 0 | Outcomes (describe instrument used): Pain: Pain threshold (kg/cm^2^) (pressure algometer) Results: Baseline: Pain: IG1 = 2.1 (1), IG2 = 2.2 (1), CG = 2.2 (1.2) Immediate post tx: Pain: IG1 = 2.5 (1.1), IG2 = 2.8 (1.3), CG = 2.6 (1.5) Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR
Hou CR (2002)279 Country: Taiwan Quality score: 2/13 Initial of reviewer: SG | Trial Design RCT Tx duration: One session Fu duration (last assessment): N screened: NR N randomized: 119 N completed tx: N attended last fu: Inclusion: Clinically active, palpable MTPs in a single side or both sides Exclusion: Neck or shoulder surgery within past yr, radiculopthy or myelopethy, history of disc disease, degenerative joint disease, fracture or dislocation in the cervical vertebrae, cognitive deficits, unwillingness to participate | Mean age (SD/range): 46.2 (13.4) yrs % of male: 8.6 Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: Myofascial TP Duration of Pain, mean (SD/range): Unknown, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1-3 (n = 8 in each grp)– ischemic compression (IC) to pain threshold (P1), 30, 60, 90 sec for grps respectively; single tx; no drop outs IG4-6 (n = 8 in each grp)– IC to Average of Pain Threshold and Pain Tolerance (P2), 30, 60, 90 sec for grps respectively IG7 (n = 21)– Hot Pack + Active ROM IG8 (n = 13)– Hot Pack + Active ROM and IC to average Pain,(30, 60 or 90 sec) IG9 (n = 9)– IG7 + TENS(30, 60 or 90 sec) IG10 (n = 10)– IG7 + stretch with spray(30, 60 or 90 sec) IG11 (n = 9)– Hot Pack + Active ROM and stretch with spray, and TENS(30, 60 or 90 sec) IG12 (n = 9)– IG7 + interferrential current and myofascial release technique (30, 60 or 90 sec) | Outcomes: Pain: Pain threshold (data not shown); pain toleranc (data not shown) e; 10 cm VAS Results- Immediate post tx: Pain (VAS) IG1 = 4.59 (0.85), IG2 = 4.72 (0.96), IG3 = 3.44 (1.14), IG4 = 3.67 (1.34), IG5 = 3.46 (1.03), IG6 = 3.57 (1.03), IG7 = 4.33 (1.82), IG8 = 3.35 (1.66), IG9 = 2.46 (1.33), IG10 = 3.26 (1.39), IG11 = 2.43 (0.65), IG12 = 2.34 (0.9) Short term: NR Intermediate: NR Long term: NR | Outcomes QoL/ well being: NR ROM- data not shown- see summary Harms: NR Summary: PPT, pain intensity, and pain tolearance were improved better in ICP1-90sec, and ICP2, 60& 90 sec vs. ICP1 30, & 60 sec or ICP2 30 sec Addition of PM such as interferential current, myofascial release, spray & stretch, or TENSE resulted in better improvement also.

Table 2.26 Neck Pain - Massage - Unknown - Non-Specific Pain

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other outcomes; Harms
Meseguer, A.A. (2006)282 Country: Spain Quality score: 6/13 Initial of reviewer: SG | Trial Design RCT Tx duration: one session Fu duration (last assessment): Post-tx N screened: NR N randomized: 54 N completed tx: 54 N attended last fu: 54 Inclusion: 19-41 yrs old with mechanical NP, tender point in the upper trapezius muscle Exclusion: widespread pain and or other symptom concomitant with fibromyalgia syndrome; whiplash injury, cervical spine surgery, radiculopathy or myelopathy determined by GP, presence of refered pain provoked by the compression of the tender spot that is diagnosis of myofascial TPs, or having undergone any tx in the cranio-cervical region. | Mean age (SD/range): IG1 = 38 (11) vs. IG2 = 43 (15) vs. CG = 39 (10) yrs % of male: 30 Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior episode of pain if acute: NR Prior CAM intervention: NR Prior surgery related to current complaint: NR | Region of pain: NP Cause of Pain: N-S Duration of Pain, mean (SD/range): Unknown, NR Severity of pain (Grading): NR Current tx/ co-intervention common in all groups: NR | Groups IG1 (n = 18) – Manipulation (stain/counter strain): gradually increasing pressure to the tender point until the sensation of pressure became one of pressure and pain, pts positioned so the palpatable tension relieved to pain reduction of 70%; one session Drop outs: NR IG2 (n = 18) – Modified manipulation (stain/ counter strain): modified version with pts arm placed in abduction; As IG1 Drop outs: NR CG (n = 18) – No Tx: after pre-intervention data pts lay supine with the cervical spine in neutral position for 5 minutes until post-intervention data were again assessed; As IG1 Drop outs: NR | Outcomes: Pain: VAS on pressure point (0-10 cm) assessed by application of 4.5 kg/cm^2^with algometer Results: Baseline: Pain: IG1 = 5.9 (2.1), IG2 = 5.1 (2.5), CG = 5.7 (2) Immediate post tx: Pain: IG1 = 3.3 (2.4), IG2 = 2.5 (1.2), CG = 5.7 (2.1) Short term: NR Intermediate: NR Long term: NR | Outcomes (describe instrument used): QoL/ well being: NR Results- mean: Baseline: NA Immediate post tx: Short term: NR Intermediate: NR Long term: NR Harms: NR

Outcomes: ODQ=Oswestry disability questionnaire; RMQ=Roland Morris Questionnaire; NPQ=Northwick Neck Pain Questionnaire; MPQ=McGill Pain Questionnaire; ODI=Oswestry Disability Index; NDI=Neck Disability Index; NHP=Nottingham Health Profile; HFAC=Hanover Functional Ability Questionnaire PDI=pain disability index; GWBS=global well-being scale; SLR=straight leg raising; GPE=global perceived effect; FTF=finger-to-floor; PPI=present pain intensity; PRI=pain rating index; PUP=pain under pressure; MRP=motion related pain; NPAD=Neck Pain and Disability Scale; QoL=Quality of Life; MVEE=maximum voluntary extension effort; PQ=pain questionnaire; MPQ=Short Form McGill Pain Questionnaire; RMAS=Roland Morris Activity Scale; QBPDS=Quebec Back Pain Disability Scale; mRDQ=modified Roland Morris Questionnarie NRS=numeric pain rating scale; PPT= pressure pain VAS=visual analogue scale;; SF= short form threshold; Special terms: HVLA=high velocity low amplitude; ETOIMS=electrical twitch-obtaining intramuscular stimulation; IMS=intramuscular stimulation; FDT= flexion distraction technique; TrP=trigger point; GP=general practitioner; CAM =complementary and alternative medicine; NSAIDs=non-steroidal anti-inflammatory drugs; NP=neck pain; N-S=non-specific; S=specific; Med=medication; PT= physiotherapy; ST=standard therapy; E-acu=electro acupuncture; MR= muscle relaxation; EX=exercise CLBP=chronic low back pain; A=baseline evaluation; B=immediately post treatment; C= short term follow up (up to 3 months post treatment); D=intermediate follow up (up to 6 months post treatment); E=long term follow up (over 6 months post treatment); acu=acupuncture; SM=spinal manipulation; LBP= low back pain; NP=neck pain; TP=thoracic pain TENS/TNS= transcutaneous electrical nerve stimulation; ROM=range of motion; MPS=myofascial pain syndrome; Mob=mobilization; ext=extension; flx=flexion; rot=rotation; MS=MS; PM=physical modalities; mA=milli Amp; Statistical: NS=statistically non-significant; SD=standard deviation; SE=standard error; WMD=weighted mean difference ; p=p-value; 95% CI= 95% Confidence Interval; SS= statistically significant; General terms: NA=not available/applicable; NR=not reported; Pt(s)=patient(s); d=day(s); mo(s)=month(s); yr(s)=year(s); wk(s)=week(s); N=number NS= not significant; pt/s= patient/s; tx=treatment/intervention Fu=follow up; ITT=intention to treat; IG=intervention group; CG=control group; RCT=randomized controlled trial; AE(s)=adverse event(s); SAE= serious adverse events; WDAE= withdrawal due to adverse events

## Cost Effectiveness

Table 3-1 CAM Back Pain II- RCTs evaluating cost effectiveness of CAM txs

Author ID Country | Study Characteristics | Population Characteristics Pain Characteristics | Intervention Detail (method, frequency, tx provider) | Efficacy/Harms Outcomes (summary data) | Economic Outcomes (summary data)
Low Back Pain
Hollinghurst, S ATEAM study (2008)178,283 Country: UK | Treatment duration: 3 mos Last assessment: 1 yr N screened: 810 N randomized (total): 579 N completed tx (total): 464 Inclusion: chronic or recurrent non S LBP from primary care Exclusion: previous experience of Alexander technique ; pts under 18 and over 65; clinical indicators of seriuos spinal disease; current nerve root pain (below knee in dermatomal distribution), previous spinal surgery, pending litigation (outcome maybe different, group too small to analyze); history of psychosis or major alcohol misuse (difficulty completing outcome); perceived inability to walk 100 m (EX difficult) | Mean age (SD/range): 45 yrs % of male: range 22% to 37% Racial composition: NR Work status employed, n (%): reported for combined grps (no EX and EX) massage 76%; Alexander technique 6 lessons 76%; 24 lessons 73%; GP care 73% Other socio-demographics married, n (%): 59% vs. 63% vs. 56% vs. 59% Co morbidities: NR Pain grading: NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 75) – Massage- not described. Therapists: NR Drop outs: at 3 mos 10, at 12 mos = 11 CG1-3 (no EX) – CG1 (n = 72)- GP care CG2 (n = 73), 6 lessons Alexander technique (AT) CG3 (n=73)- 24 lessons Alexander technique CG4-7 (with EX) CG4 (n = 71) - 6 lessons AT + EX CG5 (n = 71) - 24 lessons AT+ EX CG6 (n = 72) - Massage + EX CG7 (n = 72) - GP care + EX - prescription by GP, and up to 3 sessions of behavioral counseling with practice nurse Therapists: GP, and physiotherapists Drop outs: at 3, 12 mos CG1 = 17, 23; CG2 = 13, 15; CG3 = 13, 14; CG4 = 8, 11; CG5 16, 22; CG6 19, 22; CG7 = 19, 21 | Results: Pain: Days with back pain and troublesomeness was reported (not used for this report) Disability: Exercise & lessons in Alexander technique,but not massage, remained effective at 1 yr (compared with control Roland disability score 8.1: massage –0.58, 95% confidence interval –1.94 to 0.77, six lessons –1.40, –2.77 to –0.03, 24 lessons –3.4, –4.76 to –2.03, and EX –1.29, –2.25 to –0.34).Exercise after six lessons achieved 72% of the effect of 24 lessons alone (Roland disability score –2.98 and –4.14, respectively). Conventional care: hours of informal care (mean) range from 4.4 in CG3 to 45.8 in IG; and from 17.8 in CG7 to 44.3 in CG7 | Base yr: 2005 (1 £ UK = 1.78 USD) Reported Results: Total NHS cost over 1 yr (intervention, GP visits, other primary/ secondary care, and Med) : IG (n=64) $459.7 (363.9) CG1 (n=60) $96.9 (178.7) CG2 (n=53) $387.9 (259.8) CG3 (n=61) $1,086.5 (467.1) CG4 (n=57) $427.2 (190.3) CG5 (n=56) $1,177.4 (584.6) CG6 (n=56) $475.9 (647.1) CG7 (n=51) $274.8 (931.7) Total Personal cost (35% imputed) also reported. Conclusion: study suggests that at £20 000/ QALY thereis > 85% chance that a GP EX prescription with a nurse fu, or a short series of lessons in the AT, will be cost effective for pts with chronic or recurrent nonS back pain.
Kominski, GF (2005)157,284-291 Country: U.S. | Treatment duration: 6 wks (?) Last assessment: efficacy = 6 mos; cost = 18 mos N screened: 2355 N randomized (total): 681 N completed tx (total): 654 Inclusion: members of various HMOs who chose the 200-physicain medical groups as their primary care provider between October 1995, and Nov 1998, presented with acute to chronic non S LBP (with or without leg symptoms) Exclusion: LBP of non mechanical cause, sever coexisting conditions that threatened their 18 mos survival; blood coagulation disorder; use of anti coagulants; signs or symptoms of cauda equina syndrome; involved with third party liability or workers' compensation as a result of their LB problem | Mean age: Mean range from 49.2 to 53.6 yrs % of male: range from 42 to 53 Racial composition (%): White: 53 – 66; Black: 1.0 – 3.6; Asian/Pacific Islander: 3.1 – 6.8; Hispanic: 25.2 – 34.1; Other: 1.2 – 3.6 Work status: NR Other socio-demographics: reported education (no difference between grps) Co morbidities: NR Pain grading: NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 162)– chiropractic- SM or another spinal-adjusting technique and instruction on proper back care and EXs- mean no of visits = 6.9 Therapists: chiropractor CG1 (n = 163)- chiropractic + PM- mean no of visits = 7.5 CG2 (n = 162) – medical care- mean no of visits = 4.4 Therapists: primary care physician CG3 (n = 167)- medical care + PT- mean no of visits = 6.6 Therapist: GPs Dropouts for total sample: n=37 (4 pts in IG and 9 in CG1 dropped out at 6 mos) | Results: reported at 6 wks and 6 mos Pain: % of pts improved from baseline (2+ points) on numerical rating scales (0-10) to 2, 6-wk, and 6-mos(IG vs. CG1): - most severe pain:38%, 49%, 59% vs. 39%, 64%, 56% - average pain: 25%, 34%, 50% vs. 35%, 45%, 51% Disability: Roland Morris Disability scores (24 items) in all pts (unadjusted): reduction of about 2 points at 2 wks, 3 points at 6 wks and 4 points at 6 mos Conventional care: NR | Base yr: 1995 - 1998 Reported Results: Average LBP outPt costs in 18 mos chiropractic: $550.0 (834.0) chiropractic + PM: $565.0 (547.0) medical care: $463.0 (1255.0) medical care + PT: $765.0 (1040.0) Adjusted mean outPt costs per tx group: chiropractic: $560.0 chiropractic + PM: $579.0 medical care: $369.0 medical care + PT: $760.0 Conclusion: higher costs for chiro care without producing better clinical outcomes, The cost of medical care might have been understated due to lack of pharmaceutical data.
Niemisto, L (2003)292 Country: Finland | Treatment duration: 4 wks Last assessment: 1 yr N screened: NR N randomized (total): 204 N completed tx (total): 196 Inclusion: 24-46 yr old employed with chronic nonS LBP ≥3 mos duration and Oswestry LBP Disability Index score ≥16%; with or without radiating pain above or below knee (76% vs. 80% had radiating pain) Exclusion: malignancies, ankylosing spondylitis, sever osteoporosis, sever osteoarthritis, paralysis, progressive neurologic disease, hemophilia, spinal p p infection, previous spinal operation, vertebral fracture in last 6 mos, Sever psychiatric disease or severe sciatic with a SLR < 35° or with ≥1 recent motor deficit | Mean age (SD/range): 37 yrs % of male: 46% Racial composition: NR Work status: sick leave during the period of 1 yr, ds mean (SD): 14 (28) vs. 20 (35); employed (%) 99% vs. 91 % Other socio-demographics: NR Co morbidities: NR Pain grading: NR Current tx/ co-intervention common in all groups: pts using analgesics for back pain (%): 30% vs. 35% | Groups IG (n = 102) – Manipulation + education booklet=- muscle energy technique and stabilizing EXs aiming to correct the Iumbo-pelvic rhythm- 60 minutes- 4 times in 4 wks Therapists: experienced manual therapist Drop outs: 6 CG (n = 102) – Physician consultation + education booklet- education, instruction for postural EXs- advice on daily activities (static work, lifting, etc.)- information were reinforced at 5 mos Fu- self selected frequency of EX- Therapists: physician Drop outs: 2 | Results: Pain: VAS (mm) at 5 mos: 25.2 (23.3) vs. 36.1 (23.3) At 1 yr: 25.7 (23.3) vs. 32.2 (23.3) Disability: Oswestry Disability Index at 5 mos 14.7 (11.6) vs. 18.6 (11.6) At 1 yr: 13.7 (11.6) vs. 16.5 (11.6) Health related QoL: 5 mos: 0.88 (0.071) vs. 0.90 (0.074) 1 yr: 0.89 (0.071) vs. 0.90 (0.074) Conventional care: NR No AEs in any of the groups occurred | Base yr: 2002 Reported Results: study provided data for baseline cost (not shown); &1 yr: Total healthcare cost, mean: Manipulation (n=96) $470.0 (cost to pt= $139.0) Physician consultation (n=100) $431.0 (cost to pt= $154.0) Productivity loss -full d / half d salary: Manipulation $1,848.0 (3543.0) / $924 (1772.0) Physician consultation $2,450.0 (5163.0) / $1,229.0 (2582.0) Total cost full d / half d salary Manipulation $2,457.0 / $1,533.0 Physician consultation $3,035.0 / $1,814.0 Conclusion: the manipulative tx with stabilizing EX was more effective in reducing pain intensity and disability than the physician consultation alone.
Seferlis, T (2000)293,294 Country: Sweden | Treatment duration: 8 wks Last assessment: 1 yr N screened: NR N randomized (total): 180 N completed tx (total): 180 Inclusion: pts with acute LBP with or without sciatica requiring sick-leave; and a sick leave period for acute LBP < 2 wks before entering the study Exclusion: spine trauma or surgery, inflammatory disease, tumors of the spine, symptoms from cervical spine, thoracic spine or upper extremities, clinical symptoms or severe LB disease requiring surgery, severe/major medical disease, pregnancy, drug and or alcohol addiction, psychiatric disease/disorder and unsatisfactory knowledge of the Swedish language. | Mean age (SD): 38 yrs % of male: 53% Racial composition: NR Work status: all on sick leave < 2 wks at baseline Other socio-demographics: NR Co morbidities: NR Pain grading: NR Current tx/ co-intervention common in all groups: NR | Groups IG (n = 60)– Manual therapy- auto traction, manipulation, general Mob, auto-Mob, muscle energy technique, stretching and training co-ordination/ stability Therapists: private physical therapist Drop outs: 20 CG1 (n =60 ) – GP care - rest, sick leave, drug prescription like analgesics, anti-inflammatory drugs, advice/information about posture, self curing nature ofthe disease- -PT were often prescribed later. Therapists: physicians Drop outs: 19 CG2 (n =60 ) –intensive therapy- information, muscle e training (EX to ,muscle fatigue & muscle strength & co-ordination in abdominal gluteal, para-spinal , shoulder and lower extremity muscles), &general condition training- 3 x wk for8 wks Therapists: GPs/ PT Drop outs: 18 | Results: Pain: NA Disability: NA Conventional care: NA | Base yr: 1996 ($I USD = 6.80 SEK) Reported Results: Cost per Pt: Direct cost per Pt- Manual therapy: $1,054.26 GP care: $403.53 Intensive therapy: $1,123.24 Indirect cost per Pt- Manual therapy: $6,162.79 GP care: $7,072.06 Intensive therapy: $5,556.62 2 Total cost per Pt: Manualtherapy: $7,217.06 6 GPcare: $7,475.59 9 Intensivetherapy: $6,679.85 Total costs: Manualtherapy y $433,018.53 3 GP care $448,529.71 intensivetherapy y $400,790.74 4 Conclusion: thedirect tcosts for tx were lowest in the GP group
Ratcliffe, (2006)95,295-303 Country: UK | Treatment duration: 10 wks Last assessment: 1, and 2 yrs N screened: 289 N randomized (total): 239 N completed tx (total): 149 (group with complete data- also used for cost effectiveness analysis) Inclusion: Patients aged 18 – 65 yrs with N-S LBP of 4 – 52 wk duration (sub acute – chronic) Exclusion: Possible spinal pathology, carcinoma, motor weakness, disc prolapse, past spinal surgery, bleeding disorders, or current Acu Tx | Mean age (SD/range): 43 yrs % of male: 40% Racial composition: majority White Work status: 51.6, and 56.3% of pts were on full time work; off work due to BP n=11 in acu care, no data for usual care grp Other socio-demographics: NR Co morbidities: NR Pain grading: based on mean values, majority had mild to moderate pain at baseline Current tx/ co-intervention common in all groups: Moxibustion (17.7%), massage (42.2%), acupressure (12.8%), cupping (4.5%), Chinese herbs (4.5%), diet (11.3%), yoga EX (3.3%), relaxation (3.0%)- drugs for LBP prior to tx 88% vs. 90% | Groups IG (n = 159) – acu- 177 different bilateral & unilateral acu points (BL23, BL26, BL53, BL54, and GB30 as well as lumbar points); 25 – 40 mm long needles, 0.20 – 0.30 mm in diameter- 1285 tx were provided; the mean (range) of 8.1 (0 – 10) tx per Pt, max no. of tx was 10 for duration of 3 mos Therapists: physicians with a German diploma, 140 hrs of certified acu education Drop outs: 3 mo n=13; 1 yr n=12; 2 yrs n=36 CG (n = 80) – Usual care - Mix of PT, Med, andback EXs Therapists: NR Drop outs: 3 mos n=9; 1 yr n=12 mos; 24 mos n=21 | Results: Pain: mean Present Pain Index (McGill) at 1 yr: 1.43 (1.1) vs. 1.53 (0.9) 2 yrs: 1.42 (1.1) vs. 1.71 (1.1) Oswestry PDI (0 – 100) 1 yr: 20.6 (19.3) vs. 19.6 (15.4) 2 yrs: 18.3 (16.5) vs. 21.0 (14.2) SF-36 Bodily Pain score (0 – 100) 1 yr: 64.0 (25.6) vs. 58.3 (22.2) 2 yrs: 67.8 (24.1) vs. 59.5 (23.4) Disability: NR Conventional care: use of meds. In past 2 yrs: 40% vs. 59%; other variables also reported | Base yr: 2002-2003 Reported Results: Total NHS cost, mean (SD): Acupuncture $744.34 (539.74) Usual care 524.94(673.87) Conclusion: short course of traditional acu for persistent N-S LBP in primary care confers a modest heath benefit for minor extra cost to NHS compared with usual care.
UK BEAM trial team (UK beam study119,304,305 Country: U.K. | Treatment duration: 12 wks Last assessment: 3 mos and 1 yr N screened: 3535 N randomized (total): 1334 N completed tx (total): 1287 Inclusion: Pts aged 18-65 yrs with LBP (RMDQ => 4) who had experienced the pain daily for the past mo Exclusion: Serious spinal disorder (malignancy, OP,AS, cauda-equina, infection, or compression), previous spinal surgery, severe mental disorder, CVD, hypertension (systolic blood pressure > 180 mm Hg and diastolic > 105 mm Hg), anticoagulant Tx, steroids, RMDQ <= 3, illiterate in English | Mean age: 43 yrs % of male: 37 – 47% Racial composition: majority White (> 92%) Work status: 27 – 33% off work in past 4 wks due to LBP, or leg pain; 7 – 12% not doing work due to pain in last 4 wks Other socio-demographics: NR Co morbidities: NR Pain grading: mean values on VAS 0 – 100 reported; mean < 4.0 for all grps Current tx/ co-intervention common in all groups: NR | Groups IG (n = 342)– manipulation + best care- HVTT develop by multi-disciplinary group- 8 tx in 12 wks Therapists: chiropractors, osteopathic practitioners and physiotherapist Drop outs: CG1 (n= 322)- manipulation + EX + best care Therapists: as IG CG2 (n = 328) – best care in GP Therapists: 12 wks Drop outs: CG3 (n = 297) – best care in GP + EX Therapists: 9 classes of EX in 12 wks + GP Drop outs: | Results: Utility EQ-5D (estimated by analysis of covariance with adjustment for baseline score), mean (SD): Baseline/ 3 mo/1 yr: IG: 0.59 (0.25)/ 0.68 (0.26)/ 0.66 (0.28) CG1: 0.59 (0.24)/ 0.66 (0.24)/ 0.68 )0.59 (0.23)/ CG3 (0.26)/ 0.23 CG2 (0.26) Quality adjusted life yr (QALY)s – 1 yr, mean (SD) IG: 0.66 (0.24) 0.65 (0.24) 0.62 (0.23) 0.64 (0.25) Note: other efficacy data is presented in table UK Beam Trial Team (2004)119 | Base yr: 2000-2001 Reported Results: Total cost of health care over 12 mos (included: EX class within UK BEAM, hospital inPt stay, outPt attendance, GP consultation): Manipulation $998.69 (1417.73) Manipulation + EX $869.47 (904.54) Best care in GP $638.72 (1111.29) Best care in GP + EX $897.16 (1674.32) Conclusion: SM showed to be cost effective addition to best care by GP for back pain. Manipulation alone might give better value vs. manipulation vs. EX
Witt, CM (2006)49,306,307 Country: Germany | Treatment duration: 3 mos Last assessment: 6 mos N screened: 11630 N randomized (total): 2841 with consent form N completed tx/fu (total): 2385 Inclusion: clinical diagnosis of CLBP> 6 mos; age 18 or over, provision of written informed consent Exclusion: protrusion or prolapse > 1 intervertebral discs with concurrent neurologic symptoms; prior vertebral column surgery, infectious spondylopathy, LBP caused by inflammatory, malignant or autoimmune disease; congenital deformation of the spine, except for slight lordosis or scoliosis; compression fracture caused by osteoporosis; spinal stenosis; and spondylolysis or spondylolisthesis. | Mean age (SD/range): 53.1 (13.5) vs. 52.6 (13.2) yrs % of male: 43% Racial composition: NR Work status: NR Other socio-demographics: education (>10 yrs schooling) 25.8% vs. 29.2% Co morbidities: NR Pain grading: NR Current tx/ co-intervention common in all groups: usual care | Groups IG (n = 1451)– acu - disposable needles- at acu points decided by the treating physician- 3 mos tx phase with a maximum of 15 acu tx- 74% received 5-10 sessions; 21 % received > 10 sessions; 5% received < 5 sessions Therapists: physicians with A-diploma, a German diploma representing 140 hrs of certified acu education Drop outs: CG (n = 1390) — Delayed acu- 3 mos phase Therapists: as acu Drop outs: | Results: Pain: Back pain los (LBP rating scale) change in 3 and 6 mos from baseline- mean (95% CI) IG vs. CG: Baseline to 3 mos: 37.0 (35.2, 38.9) vs. 9.8 (7.9, 11.7) Baseline to 6 mos: 33.5 (31.4, 35.7) vs. 30.8 (28.7, 33.0) Disability- Back function loss (HFAQ), mean (95% CI) IG vs. CG: Baseline to 3 mos: 33.3 (31.4, 35.3) vs. 11.3 (9.5, 13.1) Baseline to 6 mos: 32.4 (30.3, 34.4) vs. 28.6 (26.5, 30.8) Conventional care: NR | Base yr: 2001-2004 (1 € = 1.45364 USD) Reported Results: QALYmean (SD): Baseline: 0.60 (0.11) vs. 0.61 (0.11) 3 mos: 0.69 (0.12) vs. 063 (0.11) Over the duration of study (baseline — 3 mos 12) 0.65 (0.10) vs. 0.62 (0.10) Overall cost at 3 mos post randomization, mean (SD): Acupuncture (n = 1231) $1,544.43 (3,253.57) Conventional care (n = 1157) $1,137.27 (2,513.05) Diagnostic S cost at 3 mos, mean (SD): Acupuncture (n = 1231) $809.90 (1,268.94) Conventional care (n = 1157) $366.19 (1,548.72) Conclusion:acu + routine care was associated with marked clinical improvement and was relatively cost-effective.
Neck Pain
Willich, SN (2006)209,210 Country: Germany | Treatment duration: 3 mos Last assessment: 6 mos N screened: 14161 N randomized (total): 3766 N completed tx (total): 3715 Inclusion: adults age ≥ 18 yrs of age with chronic N-S NP (> 6 mos in duration) Exclusion: prolapse of at least one intervertebral discs with concurrent neurological symptoms, prior vertebral surgery, spondylopathy, NP caused by inflammatory, cancer or autoimmune disease, congenital deformation of spine except scoliosis lordosis, compression fracture caused by osteoporosis; spinal stenosis | Mean age (SD/range): 49.8 (12.8) vs. 51.4 (13.0) yrs % of male: 30.1 % vs. 32.1% Racial composition: NR Work status: NR Other socio-demographics: > 10 yrs of schooling 31.4% vs. 30.1% Co morbidities: NR Pain grading: NR Current tx/ co-intervention common in all groups: usual care | Groups IG (n = 1753)– acu-standard acu with disposable needles permitted; 15 sessions during 3 mo Therapists: Physicians held A-diploma based on 140 h certified acu education Drop outs: 29 CG (n = 1698) – GP care- conventional Tx as needed Therapists: GP Drop outs: 22 | Results: %, mean changes from baseline (95% CI) Pain and disability: bodily pain reduction 3 mos: 28.9 (27.6; 30.2) vs. 5.8 (4.5;7.1) 6 mos: 28.0 (26.5; 29.4) vs. 25.1 (23.6; 26.5) QoL, SF-36 (increase from baseline): Physical functioning: 8.4 (7.6; 9.2) vs. 0.9 (0.2; 1.7) Role physical: 24.5 (22.6; 26.5) vs. 5.1 (3.3; 7.0) Bodily pain: 21.0 (20.0; 22.0) vs. 5.3 (4.3; 6.3) Physical component score: 5.8 (5.5; 6.2) vs. 1.2 (0.8; 1.5) | Base yr: 2004 Reported Results: Total cost, mean (SD): $1165.42 (1953.09) vs. $816.04 (1837.34) - Total diagnostic S cost: $556.40 (688.54) vs. $145.80 (930.36) - Difference in total overall cost in 6 mo: $471.61 (2106.2) vs. 36.41 (1581.28) - Difference in total diagnosis-S cost in 6 mos: $399.17 (465.88) vs. $7.41 (525.76) Conclusion: In the acu group 0.024 ± 0.004 additional QALYs were gained compared to the CG (associated with additional costs (overall: $370.03 ± 65.20; diagnosis-S: $404.16 ± 30.69). The (ICER) was $15,698.47 (overall) and $17,145.06 (diagnosis-S) per QALY gained. Therefore, for the assumed threshold value of $62,950 the additional acu intervention was cost- effective.
Lewis, M (2005)308,309 Country: UK | Treatment duration: 6 wks Last assessment: 6 mos N screened: 735 N randomized (total): 350 N completed tx (total): Inclusion: pts at least 18 yrs with clinical diagnosis of nonS NP; referred to PT by a GP with a new episode of non- S NP; no consultations other than primary health care team for NP in previous 6 mo Exclusion: weight loss, fever, progressive neurologic disorder, evidence of muscle weakness or disturbance in normal sensation, history of malignancy, inflammatory arthritis, is, polymyalgia rheumatica, osteoporosis, or gross structural or neurologic abnormality affecting the neck; pregnancy; participants with contraindications to the study tx | Mean age: 51 yrs % of male: 37% Racial composition: NR Work status (%): Employed 58;Unemployed 42; Pts off work in px 3 mo due to NP 29; Routine and manual occupations 49 Other socio-demographics: NR Co morbidities: NR Pain grading: higher mean NPQ scores and lower mean EQ-5D scores for MT group Current tx/ co-intervention common in all groups: non- steroidal anti-inflammatory drugs continued at a stable dose; advise and (A&E) delivered by study th th erapist; consultation/prescription from GP, extra PT; OTC Med, consult other health prof. | Groups IG (n = 114)– manual therapy (MT)- hands-on, passive or active assisted movements, Mobs or manipulations to the joints and soft tissues – max of 8, 20 min session over 6 wks Therapists: experienced senior musculoskeletal therapist Drop outs: 4 CG (n = 115) – A&E only (control) Therapists: as IG Drop outs: 13 CG (n =121 ) –MT + shortwave diathermy PSWD) Therapists: as era p t IG Drop outs: 8 advice and EX and manual therapy (SM) | Pain: Northwick Park Scores (NPQ, 0 - 100) , mean (SD): 6 wks: 29.6 (15.5) 25.6 (17.6) vs. 28.9 (15.5) 6 mos: 27.8 (19.4) vs. 24.2 (18.6) vs. 26.9 (18.7) Global assessment of overall change (%): Much better 6 wks: 31 vs. 27 vs. 22; 6 mos: 33 vs. 31 vs. 28 Much worse: 6 wks: 0 vs. 0 vs. 1; 6 mos: 1 vs. 2 vs. 3 Conventional care: % taking painkillers in past 48 hrs 6 wks: 55 vs. 31 vs. 43 6 mos: 54 vs. 32 vs. 52 | Base yr: 2003 Reported Results: Total healthcare resources cost at 6 mos MT(n=87): $190.69 (1742.41) A&E (n = 77): $169.10 (1735.23) PSWD (n = 94): $598.22 (10427.93) Total Societal costs (total costs of health-care resources + pts resources + productivity loss) MT(n=87): $486.81 (7321.56) A&E (n = 77): $197(1714.75) PSWD (n = 94): $543.13 (8921.38) Conclusion: the cost-effective intervention is likely to be A&E or MT, depending on the economic perspective and preferred outcome
Kothals de Bos (2005)310 Country: the Netherlands | Treatment duration: 6 wks Last assessment: 1 yr N screened: NR N randomized (total): 183 N completed tx (total): 178 Inclusion: non S NP for at least 14 ds,18-70 yrs old Exclusion: manual therapy or PT during previous 6 mos; operative surgeries in neck area or S reasons for complaints (e.g. malignant disease) | Mean age (SD/range): 45 yrs % of male: 30 – 44% Racial composition: NR Work status: n (%) pts employed ranged 71-78% Other socio-demographics: NR Co morbidities: NR Cause/duration of Pain: Pain grading: NR Current tx/ co-intervention common in all groups: home EX, Med such as paracetamol or non-steroidal antiphlogistica as usual if these not replaced by others during tx | Groups IG (n = 60)– manual therapy – Mob (muscular and spinal) , co-ordination, stabilization-45 min per session; 1 x wk Therapists: 6 registered manual therapists with min 3 yrs training Drop outs: 2 at 1 yr CG1 (n = 59) – PT- individual build-up EXs, active relaxation & relieving EXs, stretching & functional EXs- 30 min per tx; 2 x wk Therapists: 5 physiotherapists Drop outs: 0 at 1 yr CG2 (n = 64) – standard tx- heat application, EXs, paracetamol, non-steroidal antiphlogistica- 10 min visits, 2 x wk Therapists: 42 GPs Drop outs: 3 at 1 yr | Results: Pain: intensity (0-10) at 1 yr 42 (2.4) vs. 3.1 (2.9) vs. 4.1 (2.9) Disability: different of mean effects within each tx between baseline and 52 wks 7.2 (7.5) vs. 6.3 (8.0) vs. 8.5 (7.4) Conventional care: N of visits to GP, manual tx sessions, PT sessions, medical specialist care; professional home care, during one yr Other: absenteeism from paid work ; or unpaid work in one yr | Base yr: 1997-1998 Reported Results: Average LBP outPt costs in 18 mos IG = 402.0 CG = 1,166.4 CG2 = $ 1,240.2 Conclusion: manual therapy is more effective and less costly for treating NP than PT

ID = identification; RCT = randomized clinical trial; SD = SD; LBP = LBP; NP = NP:TP = TP; NS = non S; NR = NR; Acu = acu; AP = acu points; TENSE = ; fu = Fu; wk/s = wk/s; mth/s = mo/s; Tx = tx; IG = IG (only CAM interventions would use this acronym); CG = CG (used for all comparisons including CAM used in conjunction with another intervention) ES= ES; TP = TP; PP = pressure point; GP= GP; PT= physical therapy HFAQ: Hannover Functional Ability Questionnaire; HVTT= high velocity thrust technique; QALY= quality adjusted life yr All cost are reported as USD as reported in the study or converted using historic data (rates) for the yr/s indicated by authors.

## Harms

Table 4-1 CAM Back Pain II- Observational Studies Reporting Harms

Author ID Country | Study Characteristics | Population Characteristics | Pain Characteristics | Group / Intervention Detail | Outcome results: Pain, Disability | Outcome results: Other Outcomes/Harms
Cassidy, D (2008)311 Country: Canada Quality score: 8/27 | Trial Design: Case control and case-crrosover Cases n = 818 Matched controls n= 3164 Inclusion: All incident vertebrobasilar occlusion and stenosis strokes resulting in acute care hospital admission from April 1, 1993 – March 31, 2002. Exclusion: Cases that had an acute care hospital admission for any type of stroke, transient cerebral ischemia or late effects of cerebrovascular diseases before their VBA stroke admission or since April 1, 1991. | Mean age: Cases: 63.1 Control: 62.6 % of male: Cases: 63.3 Control: 63.9 Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior CAM intervention: NRs Prior surgery related to current complaint: NR | Cause of Pain: Headache / Neck Pain Duration of Pain: NA Severity of pain (Grading): NA Co-interventions: NA | Groups: Separated by age categories and doctor visit type Patients over 45 years old Patients 45 years old and younger Primary Care Physician Visits Chiropractic Visits | Outcome instruments: Pain: NA Disability: NA Results: Baseline: Pain: NA Disability: NA | Harms: Chiropractic visit in the month before the index date: Patients 45 years of age and under: (OR=3.13, 95% CI: 1.48, 6.63). Primary care physician visits in the month before the index date: Patients 45 years of age and under (OR= 3.57, 95% CI: 2.17, 5.86) Patients over 45 years of age (OR= 2.67, 95%CI: 2.25, 3.17).
Cook, C (2008)314 Country: USA Quality score: 6/27 | Trial Design: Retrosepctive cohort Group with PT: n = 75 Group without PT: n = 75 Inclusion: All patients with a primary diagnosis of mechanical low back pain, hospitalized and documented in NIS databases from 1988 to 2005 with additional codes for PT MSK manipultion, non-operative manipulation of the spine, mobilization of the spone, Exclusion: Patients younger than 18 years with any form of surgical procedure and withany form of pathlogic fracture,tumor or other mechanical low back diagnosis. | Mean age: Group with PT: 53.62 Group without PT: 50.93 % of male: Group with PT: 23% Group without PT: 22% Racial composition: Group with PT: White: 66.7% Black: 4.00% Hispanic: 2.67% Other: 3.00% Missing: 22.67% Group without PT: White: 69.33% Black: 5.33% Hispanic: 2.67% Other: 0% Missing: 22.67% Work status: NR | Cause of Pain: NA Duration of Pain: NA Severity of pain (Grading): NA Co-interventions: NA | Groups: Group with PT: Diagnosis of of mechanical LBP who received PT manual therapy Group without PT: Diagnosis of mechanical LBP who did not receive PT manual therapy | Outcome instruments: Pain: NA Disability: NA Results: Baseline:NA Pain: NA Disability: NA | Harms: Complication variables between two groups: No difference. No further description of adverse events was provided in this study.
Kohlbeck, F (2005)315 Country: USA Quality score: 12/27 | Trial Design: Prospective cohort N screened = 314 N included = 68 Inclusion: Patients that sought care at private chiro practices from Aug. 20, 2000 – Feb. 5, 2002; presented with chronic nonspecific LBP; reduced lumbopelvic flexibility; btwn 18-60 years. Exclusion: BP caused by fracture, tumor, infection, severe spondyloarthropathy; active rheumatoid disease; any active infectious disease; current history of smoking & drug/alcohol abuse; severe coexisting disease; blood coagulation disorder; any medication that would conflict with sedating meds; any conditions that would preclude the use of manipulation; lacked ability to read English; current LBP involving third-party liability or worker’s comp. | Mean age: 41.2 % of male: 61.8% Racial composition: White: 83.8 Black: 1.5% Hispanic: 7.4% Asian: 2.9% Other: 4.4% Work status: Currenly working: 92.6 Unemployed/retire d: 7.4 | Cause of Pain: Nonspecific Low Back Pain Duration of Pain: Chronic Severity of pain (Grading): 100 point scale 0-100 (most pain to least) Co-interventions: NA | Interventions: Spinal manipulation therapy only: Patients continued to receive SMT similar to initial phase of treatment. It involved a controlled dynamic thrust applied with high velocity and low amplitude, directed at 1 or more joints of the spine using short-lever contacts. Medication-assisted manipulation: MAM incorpoates the intravenous administration of sedative and analgesic medication – reducing pain and muscle spasm that hinder the effectivenss of tradition al SMT. | Outcome instruments: Pain: 0-100 point scale (most pain to least) Disability: 0-100 point scale (most disability to least) Results: Baseline: Mean Pain/Disability: 61.2 MAM vs. 71.2 SMT 6wk: 75.7 vs. 79.2 3 mo: 84.8 vs. 80.4 6 mo: 85.6 vs. 83.4 1 year: 81.3 vs. 81.0 | Harms: Treatment with medication-assisted manipulation or spinal manipulation alone for at least 4 – 6 weeks resulted in no complications. In this study spinal manipulation had been delivered by two chiropractors. In addition to the intervention treatment, participants received advice for exercise.
Rothwell, DM (2001)313 Country: Canada Quality score: 8/27 | Trial Design: Population-based nested case-control Cases n = 582 Matched controls n = 2328 Inclusion: All persons admitted to an Ontario acute care facility with a diagnosis of vertrebrobasilar dissection or occlusion from January 1993-December 1998. Exclusion: Cases who were not eligible for OHIP in the year before the reference date; Patients in chronic care facilities with prior stroke treated within the chronic care facility. | Mean age: All subjects: 60 years % of male: All subjects: 61% Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior CAM intervention: NRs Prior surgery related to current complaint: NR | Cause of Pain: NA Duration of Pain: NA Severity of pain (Grading): NA Co-interventions: NA | Groups: Cases and control Cases: Diagnosis of vertebrobasilar dissection or occlusion Control: matched by sex and age with no history of hospital admission of stroke The groups were also categorized by age into two groups 45 years and younger and over 45 years old. | Outcome instruments: Pain: NA Disability: NA Results: Baseline:NA Pain: NA Disability: NA | Harms: Case group: (Patients aged 45 years and younger) Chiroparctic visits by a week before a vertebro-basilar accident: (OR= 5.03, 95% CI: 1.3, 43.8) 3 or more vists to a chiropractic care in the month before vetrebro-basilar accident (OR= 4.98, 95% CI: 1.3, 18.6)
Smith, W.S. (2003)312 Country: USA Quality score: 10/27 | Trial Design: Nested case-control Cases n = 51 Matched controls n= 100 Inclusion: All patients evaluated for ischemic stroke or TIA from 1995 – 20000 who were aged 60 years or less at the time of the event. Exclusion: Vascular events not caused by arterial dissection | Mean age: Cases: 40.6 Control: 44.0 % of male: Cases: 41 Control: 42 Racial composition: NR Work status: NR Other socio-demographics: NR Co morbidities: NR Prior CAM intervention: NRs Prior surgery related to current complaint: NR | Cause of Pain: NA Duration of Pain: NA Severity of pain (Grading): NA Co-interventions: NA | Groups : Cases and control Cases: Had vascular event casued by arterial dissection Control: matched by sex and within 10-year age stata. | Outcome instruments: Pain: NA Disability: NA Results: Baseline:NA Pain: NA Disability: NA | Harms: % of patients with arterial dissection had SMT within 30 days = 14.0 % % of controls had SMT within 30 days = 3.0%, SMT within 30 days (Vertebral Dissection group) (OR = 6.6, 95% CI: 1.4 to 30.0).

## References

1 Huang S, Zhan H, Shi Y. Clinical lumbar function-recovering effect of different electroacupuncture points on lumbar intervertebral disc herniation. [Chinese]. Chinese J of Rehab Med. 2006;21(6):497-500.
2 Lai YZ, Zhuang LX, Zhuang ZJ, et al. [Clinical observations on needling xi-cleft points as a main treatment for the acute stage of lumbar intervertebral disc protrusion]. Shanghai J Acupunct Moxibustion. 2004;23(9):22-4.
3 Long WJ. Acupuncture treatment of acute lumbar sprain: a controlled study in 238 patients. Int J Clin Acupunct. 2000;11(1):61-4.
4 He XW, Huang JH, Zeng LY. [Observation on the therapeutic effect of warming needle moxibustion on prolapse of lumbar intervertebral disc]. [Chinese]. Zhongguo Zhen Jiu. Apr. 2007;27(4):264-6. [pmid: 17585670].
5 Araki S, Kawamura O, Mataka T, et al. [Randomized controlled trial comparing the effect of manual acupuncture with sham acupunture ofr acute low back pain]. J Japan Soc Acupunct Moxibustion. 2001;51(3):382.
6 Cao W, Wang J. Curative effect of acute lumbago with different acupuncture and moxibustion methods. Int J Clin Acupunct. 2001;12(1):21-9.
7 Eisenberg DM, Post DE, Davis RB, et al. Addition of choice of complementary therapies to usual care for acute low back pain: a randomized controlled trial. [see comment]. Spine. Jan 15. 2007;32(2):151-8. [pmid: 17224808].
8 Kennedy S, Baxter GD, Kerr DP, et al. Acupuncture for acute non-specific low back pain: a pilot randomised non-penetrating sham controlled trial. Complement Ther Med. Jun. 2008;16(3):139-46. [pmid: 18534326].
9 Kittang G, Melvaer T, Baerheim A. [Acupuncture contra antiphlogistics in acute lumbago].[see comment]. [Norwegian]. Tidsskrift for Den Norske Laegeforening. Apr 20. 2001;121(10):1207-10. [pmid: 11402745].
10 Ceccherelli F, Rigoni MT, Gagliardi G, et al. Comparison of superficial and deep acupuncture in the treatment of lumbar myofascial pain: a double-blind randomized controlled study. Clin J Pain. May. 2002;18(3):149-53. [pmid: 12048416].
11 Gunn CC, Milbrandt WE, Little AS, et al. Dry needling of muscle motor points for chronic low-back pain: a randomized clinical trial with long-term follow-up. Spine. May. 1980;5(3):279-91. [pmid: 6446774].
12 Hollisaz MT. Use of electroacupuncture for treatment of chronic sciatic pain. Internet J Pain Sypmtom Contr Palliat Care. 2006;(1):7p.
13 Itoh K, Katsumi Y, Kitakoji H. Trigger point acupuncture treatment of chronic low back pain in elderly patients--a blinded RCT. Acupunct Med. Dec. 2004;22(4):170-7. [pmid: 15628774].
14 Lian N, Liu J-B, Torres F, et al. Improvement of dermal needle and body acupuncture on pain due to lumbar strain and hyperplastic spondylitis. Chinese J Clin Rehab. 2005;9(42):161-3.
15 Wang B-X, La J-L. Therapeutic effects of electro-acupuncture and diclofenic on herniation of lumbar intervertebral disc. Chinese J Clin Rehab. 2004;8(17):3413-5.
16 Brinkhaus B, Witt CM, Jena S, et al. Acupuncture in patients with chronic low back pain: a randomized controlled trial. [see comment]. Arch Intern Med. Feb 27. 2006;166(4):450-7. [pmid: 16505266].
17 Parsons G. Acupuncture was better than no acupuncture but did not differ from minimal (sham) acupuncture for chronic low back pain at 8 weeks. [comment]. Evidence-Based Nursing. Oct. 2006;9(4):111. 2006. [pmid: 17039640].
18 Carlsson CP, Sjolund BH. Acupuncture for chronic low back pain: a randomized placebo-controlled study with long-term follow-up. Clin J Pain. Dec. 2001;17(4):296-305. [pmid: 11783809].
19 Ceccherelli F, Gagliardi G, Barbagli P, et al. [Correlation between the number of sessions and therapeutical effect in patients suffering from low back pain treated with acupuncture: a randomized controlled blind study]. [Italian]. Minerva Medica. Aug. 4 Suppl 1. 2003;94:39-44. [pmid: 15108610].
20 Cherkin DC, Eisenberg D, Sherman KJ, et al. Randomized trial comparing traditional Chinese medical acupuncture, therapeutic massage, and self-care education for chronic low back pain. Arch Intern Med. Apr 23. 2001;161(8):1081-8. [pmid: 11322842].
21 Cherkin DC, Sherman KJ, Avins AL, et al. A randomized trial comparing acupuncture, simulated acupuncture, and usual care for chronic low back pain. Arch Intern Med. May 11. 2009;169(9):858-66. [pmid: 19433697].
22 Chu J, Yuen KF, Wang BH, et al. Electrical twitch-obtaining intramuscular stimulation in lower back pain: a pilot study. [see comment]. Am J Phys Med Rehabil. Feb. 2004;83(2):104-11. [pmid: 14758296].
23 Coan RM, Wong G, Ku SL, et al. The acupuncture treatment of low back pain: a randomized controlled study. Am J Chinese Med. 1980;8(1-2):181-9.
24 Fu ZH, Chen XY, Lu LJ, et al. Immediate effect of Fu's subcutaneous needling for low back pain. Chin Med J. Jun 5. 2006;119(11):953-6. [pmid: 16780777].
25 Giles LG, Muller R. Chronic spinal pain: a randomized clinical trial comparing medication, acupuncture, and spinal manipulation. [see comment]. Spine. Jul 15. 2003;28(14):1490-502. [pmid: 12865832].
26 Muller R, Giles LG. Long-term follow-up of a randomized clinical trial assessing the efficacy of medication, acupuncture, and spinal manipulation for chronic mechanical spinal pain syndromes. J Manipulative Physiol Ther. Jan. 2005;28(1):3-11. [pmid: 15726029].
27 Grant DJ, Bishop-Miller J, Winchester DM, et al. A randomized comparative trial of acupuncture versus transcutaneous electrical nerve stimulation for chronic back pain in the elderly. Pain. Jul. 1999;82(1):9-13. [pmid: 10422654].
28 Haake M, Muller HH, Schade-Brittinger C, et al. German Acupuncture Trials (GERAC) for chronic low back pain: randomized, multicenter, blinded, parallel-group trial with 3 groups. [erratum appears in Arch Intern Med. 2007 Oct 22;167(19):2072]. Arch Intern Med. Sep 24. 2007;167(17):1892-8. [pmid: 17893311].
29 Hirota S, Itoh K, Katsumi Y. A controlled clinical trial comparing trigger point acupuncture with tender point acupuncture treatments for chronic low back pain: A pilot study on 9 elderly patients. J Japan Soc Acupunct Moxibustion. 2006;(56):67-85.
30 Inoue M, Kitakoji H, Ishizaki N, et al. Relief of low back pain immediately after acupuncture treatment--a randomised, placebo controlled trial. Acupunct Med. Sep. 2006;24(3):103-8. [pmid: 17013356].
31 Inoue M, Ktakouji H, Ikeuchi R, et al. [Randomized controlled pilot study comparing acupuncture with sham acupunture for lumbago]. J Japan Soc Acupunct Moxibustion. 2000;50(2):356.
32 Itoh K, Itoh S, Katsumi Y, et al. A pilot study on using acupuncture and transcutaneous electrical nerve stimulation to treat chronic non-specific low back pain. Complement Ther Clin Pract. Feb. 2009;15(1):22-5. [pmid: 19161950].
33 Itoh K, Katsumi Y, Hirota S, et al. Effects of trigger point acupuncture on chronic low back pain in elderly patients--a sham-controlled randomised trial. Acupunct Med. Mar. 2006;24(1):5-12. [pmid: 16618043].
34 Kerr DP, Walsh DM, Baxter D. Acupuncture in the management of chronic low back pain: a blinded randomized controlled trial. Clin J Pain. Nov. 2003;19(6):364-70. [pmid: 14600536].
35 Kwon Y, Lee S, Lee C, et al. The short-term efficacy of acupuncture for chronic low back pain: randomized sham controlled trial. J Orient Rehab Med. 2007;17(2):123-32.
36 Lehmann TR, Russell DW, Spratt KF. The impact of patients with nonorganic physical findings on a controlled trial of transcutaneous electrical nerve stimulation and electroacupuncture. Spine. Sep. 1983;8(6):625-34. [pmid: 6228019].
37 Leibing E, Leonhardt U, Koster G, et al. Acupuncture treatment of chronic low-back pain -- a randomized, blinded, placebo-controlled trial with 9-month follow-up. Pain. Mar. 2002;96(1-2):189-96. [pmid: 11932074].
38 Li N, Wu B, Wang C-W. Comparison of acupuncture-moxibustion and physiotherapy in treating chronic non-specific low back pain. [Chinese]. Chinese J Clin Rehab. 2005;9(2):186-7.
39 Macdonald AJ, Macrae KD, Master BR, et al. Superficial acupuncture in the relief of chronic low back pain. Ann R Coll Surg Engl. Jan. 1983;65(1):44-6. [pmid: 6218776].
40 Mendelson G, Selwood TS, Kranz H, et al. Acupuncture treatment of chronic back pain. A double-blind placebo-controlled trial. Am J Med. Jan. 1983;74(1):49-55. [pmid: 6217745].
41 Mendelson G, Kidson MA, Loh ST, et al. Acupuncture analgesia for chronic low back pain. Clin Exp Neurol. 1978;15:182-5. 1978.:182-5.
42 Meng CF, Wang D, Ngeow J, et al. Acupuncture for chronic low back pain in older patients: a randomized, controlled trial. Rheumatology. Dec. 2003;42(12):1508-17. [pmid: 12890859].
43 Molsberger AF, Mau J, Pawelec DB, et al. Does acupuncture improve the orthopedic management of chronic low back pain--a randomized, blinded, controlled trial with 3 months follow up. [see comment]. Pain. Oct. 2002;99(3):579-87. [pmid: 12406534].
44 Sakai T, Tsukayama H, Amagai H, et al. [Controlled trial on acupuncture for lumbago]. J Japan Soc Acupunct Moxibustion. 1998;48(1):110.
45 Sator-Katzenschlager SM, Scharbert G, Kozek-Langenecker SA, et al. The short- and long-term benefit in chronic low back pain through adjuvant electrical versus manual auricular acupuncture. [see comment]. Anesth Analg. 2004;98(5):1359-64. [pmid: 15105215].
46 Takeda H, Nabeta T. [Randomized controlled trial comparing the effect of distal pint needling with local point needling for low back pain]. J Japan Soc Acupunct Moxibustion. 2001;51(3):411.
47 Thomas M, Lundberg T. Importance of modes of acupuncture in the treatment of chronic nociceptive low back pain. Acta Anaesthesiol Scand. Jan. 1994;38(1):63-9. [pmid: 8140876].
48 Tsui ML, Cheing GL. The effectiveness of electroacupuncture versus electrical heat acupuncture in the management of chronic low-back pain. J Altern Complement Med. Oct. 2004;10(5):803-9. [pmid: 15650469].
49 Witt CM, Jena S, Selim D, et al. Pragmatic randomized trial evaluating the clinical and economic effectiveness of acupuncture for chronic low back pain. Am J Epidemiol. Sep 1. 2006;164(5):487-96. [pmid: 16798792].
50 Yeung CK, Leung MC, Chow DH. The use of electro-acupuncture in conjunction with exercise for the treatment of chronic low-back pain. J Altern Complement Med. Aug. 2003;9(4):479-90. [pmid: 14499023].
51 Yu WH, Fan WM, Cai H, et al. Clinical and mechanical studies on treatment of lumbago by needing WEIZHONG (BL40) point. Chinese Acupunct Moxibustion. 1997;17(8):503-4.
52 Yuan J, Purepong N, Hunter RF, et al. Different frequencies of acupuncture treatment for chronic low back pain: an assessor-blinded pilot randomised controlled trial. Complement Ther Med. Jun. 2009;17(3):131-40. [pmid: 19398066].
53 Chen MR, Wang P, Cheng G, et al. [Effect of warming needle moxibustion on pain threshold in the patient of sciatica]. [Chinese]. Zhongguo Zhen Jiu. Dec. 2005;25(12):831-3. [pmid: 16419700].
54 Chen XY. Observations on the efficacy of deep acupuncture of Jiaji points for treating lumbar intervertebral disc protrusion] [Chinese]. Shanghai J Acupunct Moxibustion. 2007;26(3):21-2.
55 Cui J, Xiang K, Liang YY. Scalp acupuncture and massage for treatment of prolapse of lumbar intervertebral disc and effects on immune functions] [Chinese]. Chinese Acupunct Moxibustion. 2004;24(7):445-8.
56 Ding XIY. [Clinical observations on the treatment of intervertebral disc protrusion with contralateral acupuncture]. Shanghai J Acupunct Moxibustion. 2002;21(4):24.
57 Ding YD. [Fly-probing-acupoint manipulation as a main treatment for lumbago] [Chinese]. Shanghai J Acupunct Moxibustion. 1998;17(5):25-6.
58 Guo W, Zhang H-J, Lin W-E. Effect of different acupuncture therapies in improving functional disturbance of waist and limbs in patients with multiple lumbar disc herniation at different stages. [Chinese]. Chinese J Clin Rehab. 2005;9(2):184-5.
59 Huang G-F, Zhang H-X, Zhang T-F, et al. Time-dependent analgesic effect of electroacupuncture at Jiaji acupoint in patients with lumbar disc herniation and its intervention on related factors of plasma. [Chinese]. Chinese J Clin Rehab. 2006;10(43):1-6.
60 Wang N. Acupuncture plus traction therapy for lumbar intervertebral disc protrusion: Curative effect observation. [Chinese]. J Clin Tissue Eng Res. 2007;11(25):4945-8.
61 Tang HS. [Comparative observation of corresponding channel point selection for treatment of prolapse of lumbar intervertebral disc]. [Chinese]. Zhongguo Zhen Jiu. Aug. 2008;28(8):582-4. [pmid: 18767583].
62 Jia C, Jiang G-M, Liu D-G. Effect of deep acupuncture at jiaji acupoint and acupoint-injection on lumbar disc herniation and the influence on the levels of interleukins. [Chinese]. Chinese J Clin Rehab. 2004;8(17):3324-6.
63 Mu JP, Cheng JM, Ao JB, et al. [Multiple central clinical test of electroacupuncture at Jiaji (EX-B 2) combined with laser needle-knife for treatment of lumbar disc herniation]. [Chinese]. Zhongguo Zhen Jiu. Aug. 2007;27(8):553-6. [pmid: 17853748].
64 Li D-J, Wang J, Gao Q, et al. Complementary effect of traction rotatory manipulation of lumbar spine and silver needle heat conductive treatment on lumbar disc herniation. [Chinese]. Chinese J Clin Rehab. 2006;10(47):8-11.
65 Li Q, Shang W. The effect of acupuncture plus cupping on 78 cases with lumbago. Hebei Chinese Trad Med. 1997;19(5):28.
66 Liang SY. [Observation on therapeutic effect of tendon-muscle picking therapy on myofascitis of back]. [Chinese]. Zhongguo Zhen Jiu. Aug. 2008;28(8):621-2. [pmid: 18767591].
67 Luo S. A combined treatment of scalp acupuncture and traction in 108 cases of prolapse of the lumbar intervertebral disc. J Tradit Chin Med. Sep. 2007;27(3):178-9. [pmid: 17955652].
68 Peng YY, Huang Y, et al. [Clinical study on round-sharp needle therapy combined with massage for prolapse of lumbar intervertebral disk]. Zhongguo Zhen Jiu. 2006;26(OCT):719-23. [pmid: 17117572].
69 Wu MQ. [Clinical observation on selection of acupoints on the same nerve segment for treatment of prolapxe of lumber intervertebral disc]. [Chinese]. Zhongguo Zhen Jiu. Jul. 2007;27(7):497-9. [pmid: 17722827].
70 Qu Y, Mei XD, Qu H. [Control observation of therapeutic effects on syndrome of the 3rd lumbar transverse process with thick silver warming needling and electric acupuncture][Chinese]. World J Acupunct-Moxibustion. 2006;16(3):19-22.
71 She RP. [Observation on therapeutic effect of deeply needling Qiangji 4 points on prolapse of lumbar intervertebral disc]. [Chinese]. Zhongguo Zhen Jiu. May. 2008;28(5):341-4. [pmid: 18652325].
72 Wang Y. Point-through-point acupuncture treatment of 66 patients with third lumbar vertebra transverse process syndrome] [Chinese]. Shanghai J Acupunct Moxibustion. 2004;23(2):9-10.
73 Wang Y-Q, Tang L-X, Pan C-Q. Amelioration of ventral acupuncture therapy on the pain symptom in patients with lumbar disc herniation. [Chinese]. Chinese J Clin Rehab. 2005;9(38):122-3.
74 Wu Y, Liao J, Li Q. [Clinical observation on abdominal acupuncture for treatment of 114 cases of prolapse of lumbar intervertebral disc] [Chinese]. Chinese Acupunct Moxibustion. 2004;24(11):750-2.
75 Xia FX. [41 cases of prolapse of lumbar intervertebral disc treated by complex treatment] [Chinese]. Shanghai J Acupunct Moxibustion. 1997;16(5):17.
76 Chen X. Comparative study on acupuncture needling methods for sciatica: Routine needling vs. Point-to-point penetration and deep puncture. Am J Acupunct. 1998;26(1):37-41.
77 Yao Z. Observations on the curative effect of acupuncture and moxibustion on lumbar intervertebral disc protrusion] [Chinese]. Shanghai J Acupunct Moxibustion. 2007;26(2):25-6.
78 Ye D, Zhu H. [Treat lumbar intervertebral disc protrusion( (LIDP) by electric acupuncture traction and tuina in different stages]. J Zhejiang Coll Trad Chinese Med. 2002;26(3):60.
79 Ye L, Hu YM, Zhang SL. Clinical study on treatment of prolapse of lumbar intervertebral disc with hypodermic catgut embedding therapy] [Chinese]. Chinese Acupunct Moxibustion. 2004;24(4):245-7.
80 Ye Z. [Clinical studies on the treatment of lumbar intervertebral disc protrusion with a needle knife as the main method] [Chinese]. Shanghai J Acupunct Moxibustion. 2004;23(2):11-2.
81 Zeng YF. [Clinical observations on the treatment of 67 lumbar intervertebral disc protrusions by abdomen acupuncture] [Chinese]. Shanghai J Acupunct Moxibustion. 2007;26(9):16-7.
82 Zhang D-W, Liang X-F, Wang Q-J. [Clinical research on the treatment of lumbar intervertebral disc protrusion by the combination of acupuncture and massage]. Shanghai J Acupunct Moxibustion. 2002;21(2):22.
83 Zhang BM, Wu YC, Shao P. Treatment of lumbar intervertebral disk herniation with electric acupuncture] [Chinese]. Zhen Jiu T. 2007;5(4):216-20.
84 Zhang B-M, Wu Y-C, Shao P, et al. Electro-acupuncture therapy for lumbar intervertebral disc protrusion: A randomized controlled study. [Chinese]. J Clin Tissue Eng Res. 2008;12(2):353-5.
85 Zhang HL. [A randomized controlled trial of electroacupuncture and traction for treatment of nerve-root type cervical spondylosis][Chinese]. Chinese Acupunct Moxibustion. 2003;23(11):637-9.
86 Zhang Z. [Observations on the curative effect of acupuncture and massage on lumbar intervertebral disc protrusion]. Shanghai J Acupunct Moxibustion. 2002;21(3):15.
87 Zhong B. Treatment of lumbar intervertebral disc protrusion by abdominal acupuncture plus traction] [Chinese]. Shanghai J Acupunct Moxibustion. 2006;25(6):19-20.
88 Zhou Y. [Observation of the effectiveness of prolapse of lumbar intervebral disc treated by warm needling insert Jiaji points](in Chineses). Shanghai J Acupunct Moxibustion. 1998;17(2):25.
89 Zhou YL, Liu Y, et al. [Clinical study on analgesic effect of Huaisanzhen on the nerve root pain due to prolapse of lumbar intervertebral disc]. Zhongguo Zhen Jiu. 2005;25(Jan):31-3. [pmid: 16309152].
90 Zhou YL, Zhang SQ, Sun GS, et al. [Clinical observation on ankle-three-needle for treatment of nerve root pain of prolapse of lumbar intervertebral disc]. [Chinese]. Zhongguo Zhen Jiu. Dec. 2006;26(12):847-50. [pmid: 17313003].
91 Zhou ZT. Observations on the effect of abdominal acupuncture in treating 42 cases of lumbar intervertebral disc protrusion] [Chinese]. Shanghai J Acupunct Moxibustion. 2004;23(2):13-4.
92 Zhu Q, Li SL, Min XJ. [Clinical study on treatment of prolapse of lumbar intervertebral disc by acup-moxibustion combined with autonomic traction][Chinese]. Chinese Acupunct Moxibustion. 2003;23(10):571-3.
93 He RY. Clinical observation on treatment of lumbago due to cold-dampness by warm-acupuncture plus Chinese medicine. Chinese Acupunct Moxibustion. 1997;17(5):279-80.
94 Sakai T, Tsutani K, Tsukayama H, et al. Multi-center randomized controlled trial of acupuncture with electric stimulation and acupuncture-like transcutaneous electricial nerve stimulation for lumbago. J Japan Soc Acupunct Moxibustion. 2001;51:175-84.
95 Thomas KJ, MacPherson H, Ratcliffe J, et al. Longer term clinical and economic benefits of offering acupuncture care to patients with chronic low back pain. Health Technol Assess. 2005;9(32):1-109.
96 Tsukayama H, Yamashita H, Amagai H, et al. Randomised controlled trial comparing the effectiveness of electroacupuncture and TENS for low back pain: a preliminary study for a pragmatic trial. Acupunct Med. Dec. 2002;20(4):175-80. [pmid: 12512791].
97 Zhang Y, Chen F, Wu S. [Clinical observation on O3 acupoint injection for treatment of low back pain]. [Chinese]. Zhongguo Zhen Jiu. Feb. 2007;27(2):115-6. [pmid: 17370494].
98 Lee J-W, Kim D-I. A randomized controlled trial to verify effects of Kuesu Point on low back pain and accompanied sciatica. Korean J Oriental Med. 2007;28(4):86-94.
99 Li Y, Liu Y. [Therapeutic effect of acupuncture on postoperative recovery of prolapse of lumbar intervertebral disc]. Zhongguo Zhen Jiu. 2006;26(Aug):566-8. [pmid: 16941976].
100 Wang ZX. [Clinical observation on electroacupuncture at acupoints for treatment of senile radical sciatica]. Zhongguo Zhen Jiu. Feb. 2009;29(2):126-8. [pmid: 19391537].
101 Wu YC. [Clinical observations on electroacupuncture treatment of lumbar intervertebral disc protrusion] [Chinese]. Shanghai J Acupunct Moxibustion. 2004;23(5):15-7.
102 Edelist G, Gross AE, Langer F. Treatment of low back pain with acupuncture. Can Anaesth Soc J. 1976;23(3):303-6. [pmid: 132988].
103 Garvey TA, Marks MR, Wiesel SW. A prospective, randomized, double-blind evaluation of trigger-point injection therapy for low-back pain. Spine. Sep. 1989;14(9):962-4. [pmid: 2528826].
104 Inoue M, Ktakouji H, Ikeuchi R, et al. [Randomized controlled pilot study comparing manual acupuncture with sham acupuncture for lumbago (2nd report)]. J Japan Soc Acupunct Moxibustion. 2001;51(3):412.
105 Kawase Y, Ishigami T, Nakamura H, et al. Acupuncture treatment for lower back pain: Multi-center randomized controlled trial using sham acupuncture as a control. J Japan Soc Acupunct Moxibustion. 2006;(56):140-9.
106 Kurosu Y. Acupuncture and moxibustion for lumbago (II) - Compartative experiment of the therapeutic effectiveness of acupuncture and garlic moxibustion. J Japan Soc Acupunct Moxibustion. 1979;28(2):31-4.
107 Mencke M, Wieden TE, Hoppe M, et al. Acupuncture of shoulder pain and low back pain. Two prospective double-blind studies. [German]. Akupunktur. 1988;16(4):204-15.
108 Alaksiev A, Kraev T. Postisometric relaxation versus high velocity low amplitude techniques in low back pain. Manuelle Medizin. Feb. 1996;34(1):14-7.
109 Hadler NM, Curtis P, Gillings DB, et al. A benefit of spinal manipulation as adjunctive therapy for acute low-back pain: a stratified controlled trial. Spine. Sep. 1987;12(7):703-6.
110 Hoiriis KT, Pfleger B, McDuffie FC, et al. A randomized clinical trial comparing chiropractic adjustments to muscle relaxants for subacute low back pain. J Manipulative Physiol Ther. Jul. 2004;27(6):388-98. [pmid: 15319761].
111 Hsieh CY, Adams AH, Tobis J, et al. Effectiveness of four conservative treatments for subacute low back pain: a randomized clinical trial. Spine. Jun 1. 2002;27(11):1142-8. [pmid: 12045509].
112 Morton JE. Manipulation in the treatment of acute low back pain. J Man Manip Ther. 1999;7(4):182-9.
113 Pope MH, Phillips RB, Haugh LD, et al. A prospective randomized three-week trial of spinal manipulation, transcutaneous muscle stimulation, massage and corset in the treatment of subacute low back pain. Spine. Nov 15. 1994;19(22):2571-7. [pmid: 7855683].
114 Hoehler FK, Tobis JS, Buerger AA. Spinal manipulation for low back pain. JAMA. May 8. 1981;245(18):1835-8. [pmid: 6453240].
115 Postacchini F, Facchini M, Palieri P. Efficacy of various forms of conservative treatment in low back pain. Neuro-Orthopedics. 1988;(6):28-35.
116 Rasmussen GG. Manipulation in treatment of low back pain (a randomized clinical trial. Manual Med. 1979;17(1):8-10.
117 Sanders GE, Reinert O, Tepe R, et al. Chiropractic adjustive manipulation on subjects with acute low back pain: visual analog pain scores and plasma beta-endorphin levels. J Manipulative Physiol Ther. Sep. 1990;13(7):391-5. [pmid: 2145384].
118 Shah M. Study to evaluate outcome of acute backache with drug therapy and manipulation. Manual Med. 1989;4(3):99.
119 UK BEAM Trial Team. United Kingdom back pain exercise and manipulation (UK BEAM) randomised trial: effectiveness of physical treatments for back pain in primary care. [see comment]. BMJ. Dec 11. 2004;329(7479):1377. 2004. [pmid: 15556955].
120 Buerger AA. A controlled trial of rotational manipulation in low back pain. Manuelle Medizin. 1980;18(2):17-26.
121 Cote P, Mior SA, Vernon H. The short-term effect of a spinal manipulation on pain/pressure threshold in patients with chronic mechanical low back pain. J Manipulative Physiol Ther. Jul. 1994;17(6):364-8. [pmid: 7964196].
122 Giles LG, Muller R. Chronic spinal pain syndromes: a clinical pilot trial comparing acupuncture, a nonsteroidal anti-inflammatory drug, and spinal manipulation. [see comment]. J Manipulative Physiol Ther. Jul. 1999;22(6):376-81. [pmid: 10478769].
123 Haas M, Groupp E, Kraemer DF. Dose-response for chiropractic care of chronic low back pain. Spine J. Sep. 2004;4(5):574-83. [pmid: 15363431].
124 Herzog W, Conway PJ, Willcox BJ. Effects of different treatment modalities on gait symmetry and clinical measures for sacroiliac joint patients. J Manipulative Physiol Ther. Feb. 1991;14(2):104-9. [pmid: 1826920].
125 Lalanne K, Lafond D, Descarreaux M. Modulation of the flexion-relaxation response by spinal manipulative therapy: a control group study. J Manipulative Physiol Ther. Mar. 2009;32(3):203-9. [pmid: 19362230].
126 Mohseni-Bandpei MA, Critchley J, Staunton T, et al. A prospective randomised controlled trial of spinal manipulation and ultrasound in the treatment of chronic low back pain. Physiotherapy. 2006;92(1):34-42.
127 Rasmussen J, Laetgaard J, Lindecrona AL, et al. Manipulation does not add to the effect of extension exercises in chronic low-back pain (LBP). A randomized, controlled, double blind study. Joint Bone Spine. Dec. 2008;75(6):708-13. [pmid: 19028434].
128 Triano JJ, McGregor M, Hondras MA, et al. Manipulative therapy versus education programs in chronic low back pain. Spine. Apr 15. 1995;20(8):948-55. [pmid: 7644961].
129 Waagen GN, Haldeman S, Cook G, et al. Short term trial of chiropractic adjustments for the relief of chronic low back pain. Manual Med. 1986;2:63-7.
130 Mathews W, Morkel M, Mathews J. Manipulation and traction for lumbago and sciatica: Physiotherapeutic techniques used in two controlled trials. Physiother Pract. 1988;4(4):201-6.
131 Zhang WB, Cao Y, Sun YA, et al. [Manipulative reduction for lumbar intervertebral disc herniation: a controlled clinical trial]. [Chinese]. Zhongguo Gushang. Apr. 2008;21(4):273-5. [pmid: 19102187].
132 Childs JD, Fritz JM, Flynn TW, et al. A clinical prediction rule to identify patients with low back pain most likely to benefit from spinal manipulation: a validation study.[see comment][summary for patients in Ann Intern Med. 2004 Dec 21;141(12):I39; PMID: 15611484]. Ann Intern Med. Dec 21. 2004;141(12):920-8. [pmid: 15611489].
133 Cherkin DC, Deyo RA, Battie M, et al. A comparison of physical therapy, chiropractic manipulation, and provision of an educational booklet for the treatment of patients with low back pain. [see comment]. N Eng J Med. Oct 8. 1998;339(15):1021-9.
134 Hoehler FK, Tobis JS, Buerger AA. Spinal manipulation for low back pain. JAMA. May 8. 1981;245(18):1835-8. [pmid: 6453240].
135 Bronfort G. Chiropractic versus general medical treatment of low back pain: a small scale controlled clinical trial. Am J Chiropractic Med. Dec. 1989;2(4):145-50.
136 Rupert RL, Thompson P, Wagon R. Chiropractic adjustments: Results of a controlled clinical trial in Egypt. ICA Rev. May. 1985;41(3):58-60.
137 Hoiriis K. A clinical trial comparing upper cervical and full spine chiropractic care for chronic low back pain. J Chiropr Educ. 1999;13(1):67-8.
138 Hondras MA, Long CR, Cao Y, et al. A randomized controlled trial comparing 2 types of spinal manipulation and minimal conservative medical care for adults 55 years and older with subacute or chronic low back pain. Journal of Manipulative & Physiological Therapeutics. Jun. 2009;32(5):330-43. [pmid: 19539115].
139 Dai D, Fang M, Shen G. A study on lumbar stability of degenerative spondylolisthesis treated with spine fine adjusting manipulation. [Chinese]. Chinese J of Rehab Med. 2006;21(12):1110-2.
140 Shearar KA, Colloca C, et al. A randomized clinical trial of the relative effectiveness of manual versus mechanical force chiropractic adjustments in the management of sacroiliac joint syndrome. J Chiropr Edu. 2004;18(SPR):29.
141 Hanrahan S, Van Lunen BL, Tamburello M, et al. The short-term effects of joint mobilizations on acute mechanical low back dysfunction in collegiate athletes. J Athl Training. 2005;40(2):88-93.
142 Wreje U, Nordgren B, Aberg H. Treatment of pelvic joint dysfunction in primary care--a controlled study. [erratum appears in Scand J Prim Health Care 1993 Mar;11(1):25]. Scand J Prim Health Care. Dec. 1992;10(4):310-5. [pmid: 1480873].
143 Timm KE. A randomized-control study of active and passive treatments for chronic low back pain following L5 laminectomy. The Journal of orthopaedic and sports physical therapy. 1994;20(6):276-86. [pmid: 7849747].
144 Ritvanen T, Zaproudina N, Nissen M, et al. Dynamic surface electromyographic responses in chronic low back pain treated by traditional bone setting and conventional physical therapy. [erratum appears in J Manipulative Physiol Ther. 2007 Jul-Aug;30(6):472]. J Manipulative Physiol Ther. Jan. 2007;30(1):31-7. [pmid: 17224353].
145 Mackawan S, Eungpinichpong W, Pantumethakul R, et al. Effects of traditional Thai massage versus joint mobilization on substance P and pain perception in patients with non-specific low back pain. J Bodywork Movement Ther. 2007;11(1):9-16.
146 Lopez de Celis C, Barra Lopez ME, Villar ME, et al. Effectiveness of the posteroanterior mobilization in the lumbar raquis with the Kaltenborn wedge in chronic low back pain patients [Spanish]. Fisioterapia. Nov-Dec. 2007;29(6):261-9. (30 ref) 2007;(6):261-9.
147 Hemmila HM, Keinanen-Kiukaanniemi SM, Levoska S, et al. Does folk medicine work? A randomized clinical trial on patients with prolonged back pain. Arch Phys Med Rehabil. Jun. 1997;78(6):571-7. [pmid: 9196462].
148 Hancock MJ, Maher CG, Latimer J, et al. Assessment of diclofenac or spinal manipulative therapy, or both, in addition to recommended first-line treatment for acute low back pain: a randomised controlled trial. [see comment]. Lancet. Nov 10. 2007;370(9599):1638-43. [pmid: 17993364].
149 Hurley DA, McDonough SM, Dempster M, et al. A randomized clinical trial of manipulative therapy and interferential therapy for acute low back pain. Spine. Oct 15. 2004;29(20):2207-16. [pmid: 15480130].
150 Farrell JP, Twomey LT. Acute low back pain. Comparison of two conservative treatment approaches. Medical Journal of Australia. Feb 20. 1982;1(4):160-4. [pmid: 6210835].
151 Aure OF, Nilsen JH, Vasseljen O. Manual therapy and exercise therapy in patients with chronic low back pain: a randomized, controlled trial with 1-year follow-up. [see comment]. Spine. Mar 15. 2003;28(6):525-31. [pmid: 12642755].
152 Ferreira ML, Ferreira PH, Latimer J, et al. Comparison of general exercise, motor control exercise and spinal manipulative therapy for chronic low back pain: A randomized trial. Pain. Sep. 2007;131(1-2):31-7. [pmid: 17250965].
153 Chiradejnant A, Maher CG, Latimer J, et al. Efficacy of “therapist-selected” versus “randomly selected” mobilisation techniques for the treatment of low back pain: a randomised controlled trial. Aust J Physiother. 2003;49(4):233-41. [pmid: 14632622].
154 Chiradejnant A, Latimer J, Maher CG, et al. Does the choice of spinal level treated during posteroanterior (PA) mobilisation affect treatment outcome?. Physiotherapy Theory and Practice. Dec. 2002;18(4):165-74.
155 Goodsell M, Lee M, Latimer J. Short-term effects of lumbar posteroanterior mobilization in individuals with low-back pain. J Manipulative Physiol Ther. Jun. 2000;23(5):332-42. [pmid: 10863253].
156 Konstantinou K, Foster N, Rushton A, et al. Flexion mobilizations with movement techniques: the immediate effects on range of movement and pain in subjects with low back pain. J Manipulative Physiol Ther. Mar. 2007;30(3):178-85. [pmid: 17416271].
157 Hurwitz EL, Morgenstern H, Kominski GF, et al. A randomized trial of chiropractic and medical care for patients with low back pain: eighteen-month follow-up outcomes from the UCLA low back pain study. Spine. Mar 15. 2006;31(6):611-21. [pmid: 16540862].
158 Koes BW, Bouter LM, van MH, et al. A randomized clinical trial of manual therapy and physiotherapy for persistent back and neck complaints: subgroup analysis and relationship between outcome measures. [see comment]. J Manipulative Physiol Ther. May. 1993;16(4):211-9. [pmid: 8340715].
159 MacDonald RS, Bell CMJ. An open controlled assessment of osteopathic manipulation in nonspecific low-back pain. Spine. 1990;15(5):364-70. [pmid: 2141951].
160 Powers CM, Beneck GJ, Kulig K, et al. Effects of a single session of posterior-to-anterior spinal mobilization and press-up exercise on pain response and lumbar spine extension in people with nonspecific low back pain. Physical Therapy. 2008;88(4):485-93. [pmid: 18258767].
161 Meade TW, Dyer S, Browne W, et al. Low back pain of mechanical origin: randomized comparison of chiropractic and hospital outpatient treatment. J Orthop Sports Phys Ther. 1991;13(6):278-87. [pmid: 18784399].
162 Sims-Williams H, Jayson MI, Young SM, et al. Controlled trial of mobilisation and manipulation for low back pain: hospital patients. BMJ. Nov 24. 1979;2(6201):1318-20. [pmid: 160266].
163 Cambron JA, Gudavalli MR, Hedeker D, et al. One-year follow-up of a randomized clinical trial comparing flexion distraction with an exercise program for chronic low-back pain. J Altern Complement Med. Sep. 2006;12(7):659-68. [pmid: 16970536].
164 Hawk C, Long CR, Rowell RM, et al. A randomized trial investigating a chiropractic manual placebo: a novel design using standardized forces in the delivery of active and control treatments. J Altern Complement Med. Feb. 2005;11(1):109-17. [pmid: 15750369].
165 Hawk C, Azad A, Phongphua C, et al. Preliminary study of the effects of a placebo chiropractic treatment with sham adjustments. [see comment]. J Manipulative Physiol Ther. Sep. 1999;22(7):436-43. [pmid: 10519559].
166 Beyerman KL, Palmerino MB, Zohn LE, et al. Efficacy of treating low back pain and dysfunction secondary to osteoarthritis: chiropractic care compared with moist heat alone. J Manipulative Physiol Ther. Feb. 2006;29(2):107-14. [pmid: 16461169].
167 Farasyn A, Meeusen R, Nijs J. A pilot randomized placebo-controlled trial of roptrotherapy in patients with subacute non-specific low back pain. J Back Musculoskeletal Rehabil. 2006;19(4):111-7.
168 Aleksiev A. Longitudinal comparative study on the outcome of inpatient treatment of low back pain with manual therapy vs. Physical therapy. J Orthopaedic Med. 1995;17(1):10-4.
169 Konrad K, Tatrai T, Hunka A, et al. Controlled trial of balneotherapy in treatment of low back pain. Ann Rhuem Dis. Jun. 1992;51(6):820-2.
170 Preyde M. Effectiveness of massage therapy for subacute low-back pain: a randomized controlled trial. Can Med Assoc J. Jun 27. 2000;162(13):1815-20. [pmid: 10906914].
171 Yip YB, Tse SH. The effectiveness of relaxation acupoint stimulation and acupressure with aromatic lavender essential oil for non-specific low back pain in Hong Kong: a randomised controlled trial. Complement Ther Med. Mar. 2004;12(1):28-37. [pmid: 15130569].
172 Field T, Hernandez-Reif M, Diego M, et al. Lower back pain and sleep disturbance are reduced following massage therapy. J Bodywork Movement Ther. 2007;11(2):141-5.
173 Franke A, Gebauer S, Franke K, et al. [Acupuncture massage vs Swedish massage and individual exercise vs group exercise in low back pain sufferers--a randomized controlled clinical trial in a 2 x 2 factorial design]. [German]. Forsch Komplementarmed Klass Naturheilkd. Dec. 2000;7(6):286-93. [pmid: 11155022].
174 Geisser ME, Wiggert EA, Haig AJ, et al. A randomized, controlled trial of manual therapy and specific adjuvant exercise for chronic low back pain. Clin J Pain. Nov. 2005;21(6):463-70. [pmid: 16215330].
175 Hernandez-Reif M, Field T, Krasnegor J, et al. Lower back pain is reduced and range of motion increased after massage therapy. Int J Neurosci. 2001;106(3-4):131-45. [pmid: 11264915].
176 Hsieh LL, Kuo CH, Lee LH, et al. Treatment of low back pain by acupressure and physical therapy: randomised controlled trial. [see comment]. BMJ. Mar 25. 2006;332(7543):696-700. [pmid: 16488895].
177 Hsieh LL, Kuo CH, Yen MF, et al. A randomized controlled clinical trial for low back pain treated by acupressure and physical therapy. Prev Med. Jul. 2004;39(1):168-76. [pmid: 15207999].
178 Little P, Lewith G, Webley F, et al. Randomised controlled trial of Alexander technique lessons, exercise, and massage (ATEAM) for chronic and recurrent back pain. BMJ. 2008;337:a884. 2008.:a884, 2008. [pmid: 18713809].
179 Poole H, Glenn S, Murphy P. A randomised controlled study of reflexology for the management of chronic low back pain. European Journal of Pain. Nov. 2007;11(8):878-87. [pmid: 17459741].
180 Quinn F, Hughes CM, Baxter GD. Reflexology in the management of low back pain: a pilot randomised controlled trial. Complement Ther Med. Feb. 2008;16(1):3-8. [pmid: 18346622].
181 Zaproudina N, Hietikko T, Hanninen OO, et al. Effectiveness of traditional bone setting in treating chronic low back pain: a randomised pilot trial. Complement Ther Med. Jan. 2009;17(1):23-8. [pmid: 19114225].
182 Zhang J-F, Chen W-H. Curative effect of nonoperative therapy for the lumbar disc herniation. [Chinese]. Chinese J Clin Rehab. 2004;8(11):2006-7.
183 Chatchawan U, Thinkhamrop B, Kharmwan S, et al. Effectiveness of traditional Thai massage versus Swedish massage among patients with back pain associated with myofascial trigger points. J Bodywork Movement Ther. 2005;9(4):298-309.
184 Li Z-Y, Chen P-Q, Gong L, et al. Analgesic effect on lumbar intervertebral disc protrusion-induced back-leg pain by kneading method of taking the tender point as acupoint. [Chinese]. Chinese J Clin Rehab. 2006;10(23):25-7.
185 Aigner N, Fialka C, Stocker R, et al. Acupuncture versus laser acupuncture in the treatment of whiplash injury - A prospective randomized study. [German]. Dtsch Z Akupunkt. 1999;42(1):4-12.
186 Ga H, Choi JH, Park CH, et al. Acupuncture needling versus lidocaine injection of trigger points in myofascial pain syndrome in elderly patients--a randomised trial. Acupunct Med. Dec. 2007;25(4):130-6. [pmid: 18160923].
187 Lu YX, Shan QH. [Clinical observation on treatment of cervicogenic headache with turtle-probing needling at Tianzhu (BL 10)]. [Chinese]. Zhongguo Zhen Jiu. Nov. 2006;26(11):796-8. [pmid: 17165503].
188 Irnich D, Behrens N, Gleditsch JM, et al. Immediate effects of dry needling and acupuncture at distant points in chronic neck pain: results of a randomized, double-blind, sham-controlled crossover trial. Pain. Sep. 2002;99(1-2):83-9. [pmid: 12237186].
189 Zhu XM, Polus B. A controlled trial on acupuncture for chronic neck pain. Am J Chinese Med. 2002;30(1):13-28.
190 Birch S, Jamison RN. Controlled trial of Japanese acupuncture for chronic myofascial neck pain: assessment of specific and nonspecific effects of treatment. Clin J Pain. Sep. 1998;14(3):248-55. [pmid: 9758075].
191 Li D-J, Wang J, Gao Q, et al. Interventional effects of cervical local-point traction manipulation plus silver needle heat conductive treatment for cervical spinal canal stenosis. [Chinese]. Chinese J Clin Rehab. 2006;10(43):7-10.
192 White PF, Craig WF, Vakharia AS, et al. Percutaneous neuromodulation therapy: Does the location of electrical stimulation effect the acute analgesic response?. Anesth Analg. 2000;91(4):949-54. [pmid: 11004055].
193 Lundeberg T, Eriksson SV, Lundeberg S, et al. Effect of acupuncture and naloxone in patients with osteoarthritis pain. A sham acupuncture controlled study. Pain Clinic. 1991;4(3):155-61.
194 Ceccherelli F, Tortora P, Nassimbeni C, et al. The therapeutic efficacy of somatic acupuncture is not increased by auriculotherapy: a randomised, blind control study in cervical myofascial pain. Complement Ther Med. Mar. 2006;14(1):47-52. [pmid: 16473753].
195 Thomas M, Eriksson SV, Lundeberg T. A comparative study of diazepam and acupuncture in patients with osteoarthritis pain: a placebo controlled study. Am J Chinese Med. 1991;19(2):95-100.
196 Zhao ZY, Cai D, Liang F. [Observation on therapeutic effect of Shencongding moxibustion on cervical headache] [Chinese]. Chinese Acupunct Moxibustion. 2004;24(6):389-91.
197 Yang T, Sun F, Zhou YL. [Clinical observation on acupoint sticking therapy for treatment of chronic pain of cervical intervertebral disc]. Zhongguo Zhen Jiu. Mar. 2009;29(3):197-9. [pmid: 19358501].
198 Abernethy AP. Randomized controlled trial of acupuncture for chronic neck pain. J Pain Palliat Care Pharmacother. 2008;(2):145-6. [pmid: 19042839].
199 Itoh K, Katsumi Y, Hirota S, et al. Randomised trial of trigger point acupuncture compared with other acupuncture for treatment of chronic neck pain. Complement Ther Med. Sep. 2007;15(3):172-9. [pmid: 17709062].
200 Salter GC, Roman M, Bland MJ, et al. Acupuncture for chronic neck pain: a pilot for a randomised controlled trial. BMC Musculoskelet Disord. 2006;7:99. [pmid: 17156464].
201 Seidel U, Uhlemann C. A randomised controlled double-blind trial comparing dosed lasertherapy on acupuncture points and acupuncture for chronic cervical syndrome. [German]. Dtsch Z Akupunkt. 2002;45(4):258-69.
202 Petrie JP, Hazleman BL. A controlled study of acupuncture in neck pain. Br J Rheumatol. Aug. 1986;25(3):271-5. [pmid: 3524727].
203 Petrie JP, Langley GB. Acupuncture in the treatment of chronic cervical pain. A pilot study. Clin Exp Rheumatol. Oct. 1983;1(4):333-6. [pmid: 6335859].
204 Gallacchi G, Muller W. [Acupuncture--does it contribute anything?]. [German]. Schweiz Rundsch Med Prax. May 31. 1983;72(22):778-82. [pmid: 6224144].
205 Gallacchi G, Muller W, Plattner GR, et al. [Acupuncture and laser treatment in cervical and lumbar syndrome]. [German]. Schweiz Med Wochenschr. Sep 12. 1981;111(37):1360-6. [pmid: 6457384].
206 Coan RM, Wong G, Coan PL. The acupuncture treatment of neck pain: a randomized controlled study. Am J Chinese Med. 1981;9(4):326-32.
207 David J, Modi S, Aluko AA, et al. Chronic neck pain: a comparison of acupuncture treatment and physiotherapy. Br J Rheumatol. Oct. 1998;37(10):1118-22. [pmid: 9825752].
208 Vas J, Perea-Milla E, Mendez C, et al. Efficacy and safety of acupuncture for chronic uncomplicated neck pain: a randomised controlled study. Pain. Dec 15. 2006;126(1-3):245-55. [pmid: 16934402].
209 Witt CM, Jena S, Brinkhaus B, et al. Acupuncture for patients with chronic neck pain. Pain. Nov. 2006;125(1-2):98-106. [pmid: 16781068].
210 Willich SN, Reinhold T, Selim D, et al. Cost-effectiveness of acupuncture treatment in patients with chronic neck pain. Pain. Nov. 2006;125(1-2):107-13. [pmid: 16842918].
211 Becker-Witt C, Jena S, Brinkhaus B, et al. Acupuncture in patients with chronic neck pain - the Acupuncture in Routine Care (ARC) Study. Focus Altern Complement Ther. 2004;(9):5-6.
212 Walsh N. Study backs acupuncture for headaches, neck pain. Ob/Gyn News. 2005;(February).
213 White P, Lewith G, Prescott P, et al. Acupuncture versus placebo for the treatment of chronic mechanical neck pain: a randomized, controlled trial.[see comment][summary for patients in Ann Intern Med. 2004 Dec 21;141(12):I26; PMID: 15611483]. Ann Intern Med. Dec 21. 2004;141(12):911-9. [pmid: 15611488].
214 White PJ. Abstract of The efficacy of acupuncture for the treatment of chronic mechanical neck pain - a randomised, controlled, single blind trial. Complement Ther Med. 2002;10(2):113.
215 Sator-Katzenschlager SM, Szeles JC, Scharbert G, et al. Electrical stimulation of auricular acupuncture points is more effective than conventional manual auricular acupuncture in chronic cervical pain: a pilot study. Anesth Analg. Nov. 2003;97(5):1469-73. [pmid: 14570667].
216 Nabeta T, Kawakita K. Relief of chronic neck and shoulder pain by manual acupuncture to tender points--a sham-controlled randomized trial. Complement Ther Med. Dec. 2002;10(4):217-22. [pmid: 12594972].
217 Bin X, Ling F, Lingxiang H. Clinical observation on cervical spondylopathy of the vertebroarterial type treated by electro-acupuncture. J Tradit Chin Med. 2007;27(1):39-42. [pmid: 17393625].
218 Shang X, Meng X, Dong H, et al. [Clinical observations on the treatment of nerve-root cervical spondylopathy by the combination of adjacent and remote acupoints] [Chinese]. Shanghai J Acupunct Moxibustion. 2002;21(6):12-3.
219 Li XH. [Therapeutic effect of centro-square needling Dazhui (GV 14) on cervical spondylosis] [Chinese]. Chinese Acupunct Moxibustion. 2004;24(7):455-6.
220 Lin M-N, Liu X-X, Liu J-H, et al. Needle scalpel combined with massage therapy and simple massage therapy for nerve-root type cervical spondylopathy: A randomized controlled analysis on 100 patients. Chinese J Clin Rehab. 2004;8(23):4920-1.
221 Chu J. Does EMG (dry needling) reduce myofascial pain symptoms due to cervical nerve root irritation?. Electroencephalogr Clin Neurophysiol. Aug. 1997;37(5):259-72.
222 Zhuang L-X, Zhu F-P. Effect of pressed acupuncture at baihui acupoint on thromboxane A^2^ and prostacyclin in treating vertebral artery type of cervical spondylosis. [Chinese]. Chinese J Clin Rehab. 2004;8(30):6672-3.
223 Ilbuldu E, Cakmak A, Disci R, et al. Comparison of laser, dry needling, and placebo laser treatments in myofascial pain syndrome. Photomed Laser Surg. Aug. 2004;22(4):306-11. [pmid: 15345173].
224 Zhu HZ, Quan WC, Zhang XF, et al. [Evaluation on clinical therapeutic effect of needle-knife therapy on cervical spondylosis]. [Chinese]. Zhongguo Zhen Jiu. May. 2006;26(5):316-8. [pmid: 16739840].
225 Jia CS, Shi J, Ma XS, et al. [Comparison of the analgesic effect of acupuncture between otopoint-penetrative needling and otopoint-straight needling for cervical type and nerve-root type cervicospondylopathy]. [Chinese]. Chen Tzu Yen Chiu. 2007;32(3):186-9. [pmid: 17691577].
226 Huang YF, Wang TF, Liu Y, et al. [Clinical observation on Jiquan (HT 1) for treatment of cervical spondylosis of nerve root type]. [Chinese]. Zhongguo Zhen Jiu. Jun. 2008;28(6):427-8. [pmid: 18630541].
227 Wang XL. [Observation on therapeutic effect of shu-needling therapy as main on cervical spondylosis of nerve root type]. [Chinese]. Zhongguo Zhen Jiu. Jul. 2008;28(7):497-8. [pmid: 18678161].
228 Zhang W, Zheng J, Zhao X. Treatment of arterial-type cervical spondylosis with acupoint-injection, combined with massage manipulation. Int J Clin Acupunct. 2005;14(4):261-5.
229 Fu ZH, Wang JH, Sun JH, et al. Fu's subcutaneous needling: possible clinical evidence of the subcutaneous connective tissue in acupuncture. J Altern Complement Med. Jan. 2007;13(1):47-51. [pmid: 17309377].
230 Liang ZH, Yang YH, Yu P, et al. [Logistic regression analysis on therapeutic effect of acupuncture on neck pain caused by cervical spondylosis and factors influencing therapeutic effect]. Zhongguo Zhen Jiu. Mar. 2009;29(3):173-6. [pmid: 19358495].
231 Wang C, Xiong Z, Deng C, et al. Miniscalpel-needle versus triggerpoint injection for cervical myofascial pain syndrome: a randomized comparative trial. [see comment]. J Altern Complement Med. Jan. 2007;13(1):14-6. [pmid: 17309371].
232 Zeng L. [Treatment of cervical spondylopathy by point-through-point Acupuncture] [Chinese]. Shanghai J Acupunct Moxibustion. 2005;24(7):9-10.
233 Wang XL, Huang HY. [Observation on therapeutic effect of long-time needle retention at Baihui (GV 20) on vertebroarterial cervical spondylopathy]. [Chinese]. Zhongguo Zhen Jiu. Jun. 2007;27(6):415-6. [pmid: 17663103].
234 Fu WB, Zhang HL, Fan L. [Treatment of cervical spondylopathy by needle pricking: A clinical observation of 56 cases] [Chinese]. New J Tradit Chinese Med. 2005;37(4):65-6.
235 Edwards J, Knowles N. Superficial dry needling and active stretching in the treatment of myofascial pain--a randomised controlled trial. Acupunct Med. Sep. 2003;21(3):80-6. [pmid: 14620302].
236 Buchmann J, Wende K, Kundt G, et al. Manual treatment effects to the upper cervical apophysial joints before, during, and after endotracheal anesthesia: A placebo-controlled comparison. Am J Phys Med Rehabil. 2005;84(4):251-7. [pmid: 15785257].
237 Pikula JR. The effect of spinal manipulative therapy (SMT) on pain reduction and range of motion in patients with acute unilateral neck pain: a pilot study. J Can Chiropract Assoc. Jun. 1999;43(2):111-9.
238 Yurkiw D, Mior S. Comparison of two chiropractic techniques on pain and lateral flexion in neck pain patients: a pilot study. Chiropractic Technique. Nov. 1996;8(4):155-62. (25 ref) 1996;(4):155-62.
239 Gonzalez-Iglesias J, Fernandez-de-Las-Penas C, Cleland JA, et al. Thoracic spine manipulation for the management of patients with neck pain: a randomized clinical trial. J Orthop Sports Phys Ther. Jan. 2009;39(1):20-7. [pmid: 19209478].
240 Jull GA, Stanton WR. Predictors of responsiveness to physiotherapy management of cervicogenic headache. Cephalalgia. Feb. 2005;25(2):101-8. [pmid: 15658946].
241 Sloop PR, Smith DS, Goldenberg E, et al. Manipulation for chronic neck pain. A double-blind controlled study. Spine. Nov. 1982;7(6):532-5. [pmid: 6762670].
242 Cleland JA, Childs JD, McRae M, et al. Immediate effects of thoracic manipulation in patients with neck pain: a randomized clinical trial. [see comment]. Manual Therapy. May. 2005;10(2):127-35. [pmid: 15922233].
243 Bischoff A, Nurnberger A, Voigt P, et al. Osteopathy alleviates pain in chronic non-specific neck pain: randomized controlled trial. Focus Altern Complement Ther. DEC. 2003;8(4):537.
244 Chen L, Zhang X-L, Ding H, et al. Comparative study on effects of manipulation treatment and transcutaneous electrical nerve stimulation on patients with cervicogenic headache. [Chinese]. Journal of Chinese Integrative Medicine. 2007;5(4):403-6. [pmid: 17631795].
245 Haas M, Groupp E, Aickin M, et al. Dose response for chiropractic care of chronic cervicogenic headache and associated neck pain: a randomized pilot study. J Manipulative Physiol Ther. Nov. 2004;27(9):547-53. [pmid: 15614241].
246 Nilsson N, Christensen HW, Hartvigsen J. The effect of spinal manipulation in the treatment of cervicogenic headache. J Manipulative Physiol Ther. Jun. 1997;20(5):326-30. [pmid: 9200048].
247 Whittingham W, Nilsson N. Active range of motion in the cervical spine increases after spinal manipulation (toggle recoil). J Manipulative Physiol Ther. Nov. 2001;24(9):552-5. [pmid: 11753327].
248 Sterling M, Jull G, Wright A. Cervical mobilisation: concurrent effects on pain, sympathetic nervous system activity and motor activity. Man Ther. May. 2001;6(2):72-81. [pmid: 11414776].
249 Fernandez-de-Las-Penas C, Fernandez-Carnero J, Fernandez AP, et al. Dorsal manipulation in whiplash injury treatment: A randomized controlled trial. J Whiplash Relat Disord. 2004;3(2):55-72.
250 Coppieters MW, Stappaerts KH, Wouters LL, et al. Aberrant protective force generation during neural provocation testing and the effect of treatment in patients with neurogenic cervicobrachial pain. J Manipulative Physiol Ther. 2003;26(2):99-106. [pmid: 12584508].
251 Hurwitz EL, Morgenstern H, Harber P, et al. A randomized trial of chiropractic manipulation and mobilization for patients with neck pain: clinical outcomes from the UCLA neck-pain study. [see comment]. Am J Public Health. Oct. 2002;92(10):1634-41. [pmid: 12356613].
252 Cassidy JD, Lopes AA, Yong-Hing K. The immediate effect of manipulation versus mobilization on pain and range of motion in the cervical spine: a randomized controlled trial. [see comment]. J Manipulative Physiol Ther. Nov. 1992;15(9):570-5. [pmid: 1469341].
253 Martinez-Segura R, Fernandez-de-Las-Penas C, Ruiz-Saez M, et al. Immediate effects on neck pain and active range of motion after a single cervical high-velocity low-amplitude manipulation in subjects presenting with mechanical neck pain: a randomized controlled trial. J Manipulative Physiol Ther. Sep. 2006;29(7):511-7. [pmid: 16949939].
254 Haas M, Groupp E, Panzer D, et al. Efficacy of cervical endplay assessment as an indicator for spinal manipulation. [see comment]. Spine. Jun 1. 2003;28(11):1091-6. [pmid: 12782973].
255 Vernon HT, Aker P, Burns S, et al. Pressure pain threshold evaluation of the effect of spinal manipulation in the treatment of chronic neck pain: a pilot study. J Manipulative Physiol Ther. Jan. 1990;13(1):13-6. [pmid: 2324655].
256 Cleland JA, Glynn P, Whitman JM, et al. Short-term effects of thrust versus nonthrust mobilization/manipulation directed at the thoracic spine in patients with neck pain: a randomized clinical trial. Physical Therapy. Apr. 2007;87(4):431-40. [pmid: 17341509].
257 Strunk RG, Hondras MA. A feasibility study assessing manual therapies to different regions of the spine for patients with subacute or chronic neck pain. J Chiropractic Med. Mar. 2008;7(1):1-8.
258 Kanlayanaphotporn R, Chiradejnant A, Vachalathiti R. The immediate effects of mobilization technique on pain and range of motion in patients presenting with unilateral neck pain: a randomized controlled trial. Arch Phys Med Rehab. Feb. 2009;90(2):187-92.
259 Brodin H. Cervical pain and mobilization. Acta Belgica - Medica Physica. Apr. 1983;6(2):67-72.
260 Cilliers KI, Penter CS. Relative effectiveness of two different approaches to adjust a fixated segment in the treatment of facet syndrome in the cervical spine. JNMS. 1998;(1):1-5.
261 Eqwu MO. Relative therapeutic efficacy of some vertebral mobolization techniques in the management of unilateral cervical spondylosis: a comparitive study. Journal of Physical Therapy and Science. 2008;20:103-8.
262 Cleland J. Immediate effects of throacic spine manipulation in patients with neck pain: A randomized clinical trial. J Man Manip Ther. 2004;(12):162.
263 van Schalkwyk R, Parkin-Smith GF. A clinical trial investigating the possible effect of the supine cervical rotatory manipulation and the supine lateral break manipulation in the treatment of mechanical neck pain: a pilot study. [see comment]. J Manipulative Physiol Ther. Jun. 2000;23(5):324-31. [pmid: 10863252].
264 Krauss J, Creighton D, Ely JD, et al. The immediate effects of upper thoracic translatoric spinal manipulation on cervical pain and range of motion: A randomized clinical trial. J Man Manip Ther. 2008;16(2):93-9. [pmid: 19119394].
265 Parkin-Smith GF, Penter CS. A clinical trial investigating the effect of two manipulative approaches in the treatment of mechanical neck pain: a pilot study. JNMS. 1998;(1):6-16.
266 Metcalfe S, Reese H, Sydenham R. Effect of high-velocity low-amplitude manipulation on cervical spine muscle strength: A randomized clinical trial. J Man Manip Ther. 2006;14(3):152-8.
267 Blikstad A, Gemmell H. Immediate effect of activator trigger point therapy and myofascial band therapy on non-specific neck pain in patients with upper trapezius trigger points compared to sham ultrasound: A randomised controlled trial. Clinical Chiropractic. Mar. 2008;11(1):23-9.
268 Yagci N, Uygur F, Bek N. Comparison of connective tissue massage and spray-and-stretch technique in the treatment of chronic cervical myofascial pain syndrome. Pain Clinic. 2004;16(4):469-74.
269 Irnich D, Behrens N, Molzen H, et al. Randomised trial of acupuncture compared with conventional massage and “sham” laser acupuncture for treatment of chronic neck pain. [see comment]. BMJ. Jun 30. 2001;322(7302):1574-8. [pmid: 11431299].
270 Irnich D. Randomised, placebo, controlled, multicentre trial of acupuncture for the treatment of chronic neck pain. Dtsch Z Akupunkt. 2000;43(1):40.
271 Cen SY, Loy SF, Sletten EG, et al. The effect of traditional Chinese Therapeutic Massage on individuals with neck pain. Clinical Acupuncture and Oriental Medicine. 2003;4(2-3):88-93.
272 Zaproudina N, Hanninen OO, Airaksinen O. Effectiveness of traditional bone setting in chronic neck pain: randomized clinical trial. J Manipulative Physiol Ther. Jul. 2007;30(6):432-7. [pmid: 17693333].
273 Sherman KJ, Cherkin DC, Hawkes RJ, et al. Randomized trial of therapeutic massage for chronic neck pain. Clin J Pain. Mar. 2009;25(3):233-8. [pmid: 19333174].
274 Zhang Y-Z, Wang X-H, Xing H-Y, et al. Mechanical effects of traction and massage therapy on cervical spondylopathy. Chinese J Clin Rehab. 2005;9(42):159-61.
275 Fernandez-de-Las-Penas C, Alonso-Blanco C, Fernandez-Carnero J, et al. The immediate effect of ischemic compression technique and transverse friction massage on tenderness of active and latent myofascial trigger points: A pilot study. J Bodywork Movement Ther. 2006;10(1):3-9.
276 Gemmell H, Miller P, Nordstrom H. Immediate effect of ischaemic compression and trigger point pressure release on neck pain and upper trapezius trigger points: A randomised, controlled trial. Clinical Chiropractic. Mar. 2008;11(1):30-6.
277 Hemmila HM. Bone setting for prolonged neck pain: a randomized clinical trial. J Manipulative Physiol Ther. Sep. 2005;28(7):508-15. [pmid: 16182025].
278 Hanten WP, Barrett M, Gillespie-Plesko M, et al. Effects of active head retraction with retraction/extension and occipital release on the pressure pain threshold of cervical and scapular trigger points. Physiotherapy Theory and Practice. 1997;13(4):285-91.
279 Hou CR, Tsai LC, Cheng KF, et al. Immediate effects of various physical therapeutic modalities on cervical myofascial pain and trigger-point sensitivity. Arch Phys Med Rehab. Oct. 2002;83(10):1406-14.
280 Fryer G, Hodgson L. The effect of manual pressure release on myofascial trigger points in the upper trapezius muscle. J Bodywork Movement Ther. 2005;9(4):248-55.
281 Hodgson L, Fryer G. The effect of manual pressure release on myofascial trigger points in the upper trapezius muscle. International Journal of Osteopathic Medicine. 2006;9(JUN):33.
282 Meseguer AA, Fernandez-de-Las-Penas C, Navarro-Poza JL, et al. Immediate effects of the strain/counterstrain technique in local pain evoked by tender points in the upper trapezius muscle. Clinical Chiropractic. Sep. 2006;9(3):112-8. (24 ref) 2006;9(3):112-8.
283 Hollinghurst S, Sharp D, Ballard K, et al. Randomised controlled trial of Alexander technique lessons, exercise, and massage (ATEAM) for chronic and recurrent back pain: economic evaluation. BMJ. 2008;337:a2656. [pmid: 19074232].
284 Kominski GF, Heslin KC, Morgenstern H, et al. Economic evaluation of four treatments for low-back pain: results from a randomized controlled trial. [see comment]. Med Care. May. 2005;43(5):428-35. [pmid: 15838406].
285 Hurwitz EL, Morgenstern H, Yu F. Satisfaction as a predictor of clinical outcomes among chiropractic and medical patients enrolled in the UCLA low back pain study. Spine. Oct 1. 2005;30(19):2121-8. [pmid: 16205336].
286 Goldstein MS, Morgenstern H, Hurwitz EL, et al. The impact of treatment confidence on pain and related disability among patients with low-back pain: results from the University of California, Los Angeles, low-back pain study. Spine J. Nov. 2002;2(6):391-9. [pmid: 14589256].
287 Hurwitz EL, Morgenstern H, Harber P, et al. A randomized trial of medical care with and without physical therapy and chiropractic care with and without physical modalities for patients with low back pain: 6-month follow-up outcomes from the UCLA low back pain study. [see comment]. Spine. Oct 15. 2002;27(20):2193-204. [pmid: 12394892].
288 Hertzman-Miller RP, Morgenstern H, Hurwitz EL, et al. Comparing the satisfaction of low back pain patients randomized to receive medical or chiropractic care: results from the UCLA low-back pain study. Am J Public Health. Oct. 2002;92(10):1628-33. [pmid: 12356612].
289 Hurwitz EL, Morgenstern H, Harber P, et al. The effectiveness of physical modalities among patients with low back pain randomized to chiropractic care: Findings from the UCLA low back pain study. J Manipulative Physiol Ther. 2002;25(1):10-20. [pmid: 11898014].
290 Hurwitz EL, Morgenstern H, Harber PI, et al. Effectiveness of physical modalities among low back pain patients randomized to chiropractic care: findings from the UCLA low-back pain study. Eur J Chiropr. 2002;49(1):102-3.
291 Hoving JL, Korthals-de BI, De VH, et al. The effects and costs of manual therapy, physiotherapy and treatment by the general practitioner in neck disorders: A randomized clinical experiment. [Dutch]. Huisarts en Wetenschap. 2004;47(5):218-26.
292 Niemisto L, Lahtinen-Suopanki T, Rissanen P, et al. A randomized trial of combined manipulation, stabilizing exercises, and physician consultation compared to physician consultation alone for chronic low back pain. Spine. Oct 1. 2003;28(19):2185-91. [pmid: 14520029].
293 Seferlis T, Lindholm L, Nemeth G. Cost-minimisation analysis of three conservative treatment programmes in 180 patients sick-listed for acute low-back pain. Scand J Prim Health Care. Mar. 2000;18(1):53-7. [pmid: 10811045].
294 Seferlis T, Nemeth G, Carlsson AM, et al. Conservative treatment in patients sick-listed for acute low-back pain: a prospective randomised study with 12 months' follow-up. Eur Spine J. 1998;7(6):461-70. [pmid: 9883955].
295 Ratcliffe J, Thomas KJ, MacPherson H, et al. A randomised controlled trial of acupuncture care for persistent low back pain: cost effectiveness analysis[see comment]. BMJ. Sep 23. 2006;333(7569):626. 2006. [pmid: 16980315].
296 Thomas KJ, MacPherson H, Thorpe L, et al. Randomised controlled trial of a short course of traditional acupuncture compared with usual care for persistent non-specific low back pain[see comment]. BMJ. Sep 23. 2006;333(7569):623. 2006. [pmid: 16980316].
297 Thomas K, MacPherson H, Ratcliffe J, et al. A short course of acupuncture is a cost-effective intervention for low back pain in primary care. Results from a pragmatic randomised controlled.[record]. Cochrane Library. 2009;(4):CN-00519332.
298 Thorpe L, Thomas K, Fitter M, et al. Early results from a pragmatic randomised controlled trial demonstrate acceptability and potential effectiveness of acupuncture as a treatment for low back pain [abstract]. The Challenge of Collaboration Proceedings of the 18th Annual Meeting of the International Society of Technology Assessment in Health Care. Jun 9 12. 2002. 2002:204.
299 MacPherson H. Acupuncture and low back pain: Results from a pragmatic randomised controlled trial. J Altern Complement Med. 2004;10(1):204-5.
300 Thorpe L, Thomas KJ, Fitter M, et al. Acupuncture in the management of persistent low back pain: findings to date of a pragmatic, randomised controlled trial. Focus Altern Complement Ther. 2002;7(1):113.
301 MacPherson H, Thomas K, Brazier J, et al. Longer term clinical and economic benefits of offering acupuncture to patients with chronic low back pain assessed as suitable for primary care management - 3 month clinical outcomes from a controlled trial of 241 patients. Acupunct Med. 2002;20(3-Feb):121.
302 Thomas K, Thorpe L, MacPherson H. Preliminary findings from a pragmatic randomised controlled trial demonstrate acceptability of acupuncture as a treatment for low back pain. Clin Acupunct Orient Med. 2003;4(1):56.
303 Thomas KJ, MacPherson H, Ratcliffe J, et al. Longer term clinical and economic benefits of offering acupuncture care to patients with chronic low back pain (Structured abstract). Health Technology Assessment. 2005;9(32):140.
304 UK BEAM Trial Team. United Kingdom back pain exercise and manipulation (UK BEAM) randomised trial: cost effectiveness of physical treatments for back pain in primary care.[see comment]. BMJ. Dec 11. 2004;329(7479):1381. 2004. [pmid: 15556954].
305 Ernst E, Tillett R, Tveito TH, et al. United Kingdom back pain exercise and manipulation (UK BEAM) trial UK BEAM Trial Team United Kingdom back pain exercise and manipulation (UK BEAM) randomised trial: effectiveness of physical treatments for back pain in primary care. BMJ. 2004;329:1377-81. 11. December. BMJ 2005 Mar 19; 330(7492): 673-4 (11 ref) 2005;(7492):673-4. [pmid: 15556955].
306 Witt CM, Brinkhaus B, Reinhold T, et al. Efficacy, effectiveness, safety and costs of acupuncture for chronic pain - Results of a large research initiative. Acupunct Med. Suppl. 2006;24:S33-S39.
307 Witt C, Selim D, Reinhold T, et al. Cost-effectiveness of acupuncture in patients with headache, low back pain and osteoarthritis of the hip and the knee. 12th Annual Symposium on Complementary Health Care -- Abstracts. 19th-21st September. 2005. Exeter, UK. Focus Altern Complement Ther. 2005:57-8.
308 Lewis M, James M, Stokes E, et al. An economic evaluation of three physiotherapy treatments for non-specific neck disorders alongside a randomized trial. Rheumatology. Nov. 2007;46(11):1701-8. [pmid: 17956916].
309 Dziedzic K, Hill J, Lewis M, et al. Effectiveness of manual therapy or pulsed shortwave diathermy in addition to advice and exercise for neck disorders: a pragmatic randomized controlled trial in physical therapy clinics. Arthrit Rheum. Apr 15. 2005;53(2):214-22.
310 Korthals de Bos I, Hoving JL, van Tulder MW, et al. Cost effectiveness of physiotherapy, manual therapy, and general practitioner care for neck pain: economic evaluation alongside a randomised controlled trial. [see comment]. BMJ. Apr 26. 2003;326(7395):911. 2003. [pmid: 12714472].
311 Cassidy JD, Boyle E, Cote P, et al. Risk of vertebrobasilar stroke and chiropractic care: results of a population-based case-control and case-crossover study. J Manipulative Physiol Ther. Feb. 2 Suppl. 2009;32:S201-S208. [pmid: 19251066].
312 Smith WS, Johnston SC, Skalabrin EJ, et al. Spinal manipulative therapy is an independent risk factor for vertebral artery dissection. [see comment]. Neurology. May 13. 2003;60(9):1424-8. [pmid: 12743225].
313 Mulligan BR. Manual therapy: Nags Snags MWMS etc. Wellington, NZ. Plane View Services. 1999.
314 Cook C, Cook A, Worrell T. Manual therapy provided by physical therapists in a hospital-based setting: a retrospective analysis. J Manipulative Physiol Ther. Jun. 2008;31(5):338-43. [pmid: 18558275].
315 Kohlbeck FJ, Haldeman S, Hurwitz EL, et al. Supplemental care with medication-assisted manipulation versus spinal manipulation therapy alone for patients with chronic low back pain. J Manipulative Physiol Ther. May. 2005;28(4):245-52. [pmid: 15883577].