# Sample Data Abstraction Forms

General Data

Data element | Comments, coding
Ref id
First author, year
Companion ref id
Inclusion Criteria
Exclusion Criteria
country/ region in which study was conducted
N assessed for eligibility
Intervention
Intervention description | (if applicable)
dose, frequency of treatment, duration of treatment
Type of treatment provider | (describe in brief)
mean n of treatments / study period
SD [SEM] treatments
N of patient in each group
Mean age
SD age [SEM age]
Males %
Ethnicity %
Work status | (i.e. unemployed= n/N, %)- if this outcome is reported for end of treatment, please fill in the corresponding worksheet
Education status | (i.e. post secondary education= n/N, %)
Other social status data | (provide detail)
Previous surgery related to pain (n)
Co-interventions | (describe per group)
Co-morbidities | (describe and provide number for each group)
Location of pain | low back (LBP) neck (NP) thorax (TP)
Pain Grading | (categories of intensity)
Duration of pain | acute (0 - 4 weeks) subacute (4 - 12 weeks) chronic (=/> 12 weeks) unknown (mix)
mean duration of pain
SD duration of pain | (convert SEM to SD)
Past episodes of pain if acute
Specify cause of pain | NS = Non Specific 1 = disc/joint disease 2 = spinal stenosis 3 = facet joint syndrome 4 = spondylosysis 5 = osteoporotic fracture 6 = myofascial pain 7 = degenerative disease 8 = whiplash 9 = mechanical 10 = work related 11 = cervico-genic 12 = radiculopathy 13 = mixed specific (flag this) NR = Not reported
n (%) with radiating pain
List all relevant outcomes/instruments evaluated in this study (at which time point)
Patients lost at each follow up | A = Baseline B = Immediate followup C = Short term followup D = Intermediate term followup E = Long term followup
Overall conclusions on efficacy from an abstract if no/little results reported
Additional Comments or important notes about this study

Abbreviations: tx = treatment; SD = Standard Deviation, AE = Adverse Events, % = Percent SEM = Standard Error of the Mean

Pain Data

Data element | Comments, coding for data extraction
Ref id
First author, year
Intervention groups | (number each group 1-10)
comparison groups | (group 1 vs. group 2)
Instrument/s (describe full detail of the instrument used, use as many rows as needed to include all reported) | VAS (0-100) for pain PDI n of words Other (specify each instrument in the respective cell of the worksheet to which you are extracting)
Baseline
N evaluated / group
Baseline mean
Baseline SD
Intermediate follow-up
N evaluated
Post treatment mean
Post treatment SD
Mean change from baseline
Change from baseline SD
95% CI- Low
95% CI- High
P value
Between group difference in post treatment mean | (in column E clearly state which group is being subtracted from which group. Also be mindful of the sign of the difference [+ or -])
Between group difference SD
95% CI- Low
95% CI- High
P value
Between group difference in mean changes from baseline
Between group difference SD
95% CI- Low
95% CI- High
P value
n of patients with > 50% or 100% pain reduction | (please specify)
% of patients with >50% or 100% pain reduction
Risk Ratio
Risk difference
95% CI- Low
95% CI- High
P value
Short term follow-up
N evaluated / group
Post tx mean
Post tx SD
Mean change from baseline
Change from baseline SD
95% CI- Low
95% CI- High
P value
between group difference in mean changes from baseline
between group difference SD
95% CI- Low
95% CI- High
P value
n of patients with > 50% or 100% pain reduction
% of patients with >50% or 100% pain reduction
Risk ratio
Risk difference
95% CI- Low
95% CI- High
P value
Intermediate follow-up
N evaluated / group
Post tx mean
Post tx SD
Mean change from baseline
Change from baseline SD
95% CI- Low
95% CI- High
P value
between group difference in mean changes from baseline
between group difference SD
95% CI- Low
95% CI- High
P value
n of patients with > 50% or 100% pain reduction (please specify)
% of patients with >50% or 100% pain reduction
Risk ratio
Risk difference
95% CI- Low
95% CI- High
P value
Long Term follow-up
N evaluated / group
Post tx mean
Post tx SD
Mean change from baseline
Change from baseline SD
95% CI- Low
95% CI- High
P value
between group difference in mean changes from baseline
between group difference SD
95% CI- Low
95% CI- High
P value
n of patients with > 50% or 100% pain reduction (please specify)
% of patients with >50% or 100% pain reduction
Risk ratio
Risk difference
95% CI- Low
95% CI- High
P value

Abbreviations: tx= treatment; SD = Standard Deviation, AE = Adverse Events, % = Percent SEM = Standard Error of the Mean

Function / Disability Data

Data element | Comments, coding for data extraction
Ref id
First author, year
Intervention groups | (number each group 1-10)
comparison groups | (group 1 vs. group 2)
Instrument/s (describe full detail of the instrument used, use as many rows as needed to include all reported) | VAS (0-100) for pain PDI n of words Other (specify each instrument in the respective cell of the worksheet to which you are extracting)
Baseline
N evaluated / group
Baseline mean
Baseline SD
Intermediate follow-up
N evaluated
Post treatment mean
Post treatment SD
Mean change from baseline
Change from baseline SD
95% CI- Low
95% CI- High
P value
Between group difference in post treatment mean | (in column E clearly state which group is being subtracted from which group. Also be mindful of the sign of the difference [+ or -])
Between group difference SD
95% CI- Low
95% CI- High
P value
Between group difference in mean changes from baseline
Between group difference SD
95% CI- Low
95% CI- High
P value
n of patients with > 50% or 100% pain reduction | (please specify)
% of patients with >50% or 100% pain reduction
Risk Ratio
Risk difference
95% CI- Low
95% CI- High
P value
Short term follow-up
N evaluated / group
Post tx mean
Post tx SD
Mean change from baseline
Change from baseline SD
95% CI- Low
95% CI- High
P value
between group difference in mean changes from baseline
between group difference SD
95% CI- Low
95% CI- High
P value
n of patients with > 50% or 100% pain reduction
% of patients with >50% or 100% pain reduction
Risk ratio
Risk difference
95% CI- Low
95% CI- High
P value
Intermediate follow-up
N evaluated / group
Post tx mean
Post tx SD
Mean change from baseline
Change from baseline SD
95% CI- Low
95% CI- High
P value
between group difference in mean changes from baseline
between group difference SD
95% CI- Low
95% CI- High
P value
n of patients with > 50% or 100% pain reduction (please specify)
% of patients with >50% or 100% pain reduction
Risk ratio
Risk difference
95% CI- Low
95% CI- High
P value
Long Term follow-up
N evaluated / group
Post tx mean
Post tx SD
Mean change from baseline
Change from baseline SD
95% CI- Low
95% CI- High
P value
between group difference in mean changes from baseline
between group difference SD
95% CI- Low
95% CI- High
P value
n of patients with > 50% or 100% pain reduction (please specify)
% of patients with >50% or 100% pain reduction
Risk ratio
Risk difference
95% CI- Low
95% CI- High
P value

Abbreviations: tx= treatment; SD = Standard Deviation, AE = Adverse Events, % = Percent SEM = Standard Error of the Mean

Quality of Life Data

Data element | Comments, coding for data extraction
Ref id
First author, year
Intervention groups | (number each group 1-10)
comparison groups | (group 1 vs. group 2)
Instrument/s (describe full detail of the instrument used, use as many rows as needed to include all reported) | VAS (0-100) for pain PDI n of words Other (specify each instrument in the respective cell of the worksheet to which you are extracting)
Baseline
N evaluated / group
Baseline mean
Baseline SD
Intermediate follow-up
N evaluated
Post treatment mean
Post treatment SD
Mean change from baseline
Change from baseline SD
95% CI- Low
95% CI- High
P value
Between group difference in post treatment mean | (in column E clearly state which group is being subtracted from which group. Also be mindful of the sign of the difference [+ or -])
Between group difference SD
95% CI- Low
95% CI- High
P value
Between group difference in mean changes from baseline
Between group difference SD
95% CI- Low
95% CI- High
P value
n of patients with > 50% or 100% pain reduction | (please specify)
% of patients with >50% or 100% pain reduction
Risk Ratio
Risk difference
95% CI- Low
95% CI- High
P value
Short term follow-up
N evaluated / group
Post tx mean
Post tx SD
Mean change from baseline
Change from baseline SD
95% CI- Low
95% CI- High
P value
between group difference in mean changes from baseline
between group difference SD
95% CI- Low
95% CI- High
P value
n of patients with > 50% or 100% pain reduction
% of patients with >50% or 100% pain reduction
Risk ratio
Risk difference
95% CI- Low
95% CI- High
P value
Intermediate follow-up
N evaluated / group
Post tx mean
Post tx SD
Mean change from baseline
Change from baseline SD
95% CI- Low
95% CI- High
P value
between group difference in mean changes from baseline
between group difference SD
95% CI- Low
95% CI- High
P value
n of patients with > 50% or 100% pain reduction (please specify)
% of patients with >50% or 100% pain reduction
Risk ratio
Risk difference
95% CI- Low
95% CI- High
P value
Long Term follow-up
N evaluated / group
Post tx mean
Post tx SD
Mean change from baseline
Change from baseline SD
95% CI- Low
95% CI- High
P value
between group difference in mean changes from baseline
between group difference SD
95% CI- Low
95% CI- High
P value
n of patients with > 50% or 100% pain reduction (please specify)
% of patients with >50% or 100% pain reduction
Risk ratio
Risk difference
95% CI- Low
95% CI- High
P value

Abbreviations: tx= treatment; SD = Standard Deviation, AE = Adverse Events, % = Percent SEM = Standard Error of the Mean

Work Data

Data element | Comments, coding for data extraction
Ref id
First author, year
Intervention groups | (number each group 1-10)
comparison groups | (group 1 vs. group 2)
Instrument/s (describe full detail of the instrument used, use as many rows as needed to include all reported) | VAS (0-100) for pain PDI n of words Other (specify each instrument in the respective cell of the worksheet to which you are extracting)
Baseline
N evaluated / group
N at full time work
N at part time sick leave
N at full time sick leave
continuous measures of work | (specify: unemployed; homemaker; retired- all not due to pain)
Other – mean
Other- SD (SEM)
Other data | (describe with numeric details)
Intermediate follow-up
N of patient at full time work
Risk ratio
Odds ratio
Risk difference
95% CI- Low
95% CI- High
P value
N of patient at part time sick leave
Risk ratio
Odds ratio
Risk difference
95% CI- Low
95% CI- High
P value
N of patient at full time sick leave
Risk ratio
Odds ratio
Risk difference | (please specify)
95% CI- Low
95% CI- High
P value
Other- continues measure, specify
Other post tx- mean
Other- post tx SD [SEM]
95% CI- Low
95% CI- High
P value
Other dichotomous measure, provide numeric data, n
Risk ratio [odds ratio]
95% CI- Low
95% CI- High
Short term followup
N of patient at full time work
Risk ratio
Odds ratio
Risk difference
95% CI- Low
95% CI- High
P value
N of patient at part time sick leave
Risk ratio
Odds ratio
Risk difference
95% CI- Low
95% CI- High
P value
N of patient at full time sick leave
Risk ratio
Odds ratio
Risk difference | (please specify)
95% CI- Low
95% CI- High
P value
Other- continues measure, specify
Other post tx- mean
Other- post tx SD [SEM]
95% CI- Low
95% CI- High
P value
Other dichotomous measure, provide numeric data, n
Risk ratio [odds ratio]
95% CI- Low
95% CI- High
Intermediate followup
N of patient at full time work
Risk ratio
Odds ratio
Risk difference
95% CI- Low
95% CI- High
P value
N of patient at part time sick leave
Risk ratio
Odds ratio
Risk difference
95% CI- Low
95% CI- High
P value
N of patient at full time sick leave
Risk ratio
Odds ratio
Risk difference | (please specify)
95% CI- Low
95% CI- High
P value
Other- continues measure, specify
Other post tx- mean
Other- post tx SD [SEM]
95% CI- Low
95% CI- High
P value
Other dichotomous measure, provide numeric data, n
Risk ratio [odds ratio]
95% CI- Low
95% CI- High
Long Term followup
N of patient at full time work
Risk ratio
Odds ratio
Risk difference
95% CI- Low
95% CI- High
P value
N of patient at part time sick leave
Risk ratio
Odds ratio
Risk difference
95% CI- Low
95% CI- High
P value
N of patient at full time sick leave
Risk ratio
Odds ratio
Risk difference | (please specify)
95% CI- Low
95% CI- High
P value
Other- continues measure, specify
Other post tx- mean
Other- post tx SD [SEM]
95% CI- Low
95% CI- High
P value
Other dichotomous measure, provide numeric data, n
Risk ratio [odds ratio]
95% CI- Low
95% CI- High

Abbreviations: tx= treatment; SD = Standard Deviation, AE = Adverse Events, % = Percent SEM = Standard Error of the Mean

Utility - HealthCare Data

Data element | Comments, coding for data extraction
Ref id
First author, year
Intervention groups | (number each group 1-10)
Comparison groups | (group 1 vs. group 2)
Instrument/s (describe full detail of the instrument used, use as many rows as needed to include all reported) | VAS (0-100) for pain PDI n of words Other (specify each instrument in the respective cell of the worksheet to which you are extracting)
Baseline Conventional care | Continuous outcomes
N evaluated
Describe outcome | (units of measure)
Baseline mean
Baseline SD
Between group difference in post treatment mean
SEM | (convert SD to SEM)
95% CI- Low
95% CI- High
P value
Between group difference in mean changes from baseline
SEM | (convert SD to SEM)
95% CI- Low
95% CI- High
P value
Baseline Conventional Care | Dichotomous data
Describe conventional care used and units | (diagnostic procedure, treatment sessions per patient per duration, etc.)
Reported n for column AE
Reported % for Column AE
Risk ratio
Odds ratio
Risk difference
95% CI- Low
95% CI- High
P value
Post Treatment Conventional care | Continuous outcomes
N evaluated
Describe outcome | (units of measure)
Baseline mean
Baseline SD
Between group difference in post treatment mean
SEM | (convert SD to SEM)
95% CI- Low
95% CI- High
P value
Between group difference in mean changes from baseline
SEM | (convert SD to SEM)
95% CI- Low
95% CI- High
P value
Post Treatment Conventional Care | Dichotomous data
Describe conventional care used and units | (diagnostic procedure, treatment sessions per patient per duration, etc.)
Reported n for column AE
Reported % for Column AE
Risk ratio
Odds ratio
Risk difference
95% CI- Low
95% CI- High
P value

Abbreviations: tx= treatment; SD = Standard Deviation, AE = Adverse Events, % = Percent SEM = Standard Error of the Mean

Cost Data

Data element | Comments, coding for data extraction
Ref id
First author, year
Intervention groups | (number each group 1-10)
Comparison groups | (group 1 vs. group 2)
Instrument/s (describe full detail of the instrument used, use as many rows as needed to include all reported) | VAS (0-100) for pain PDI n of words Other (specify each instrument in the respective cell of the worksheet to which you are extracting)
Unit of cost | (for example US dollars)
Cost 1 | (cost in health care sector, cost of production loss, costs in other sectors, patient and family costs, total costs)
N evaluated
Cost 1 | (describe all, including method of calculation)
Cost 1, mean
Cost 1, SD | (convert SEM to SD)
Between group difference in cost per treatment | in column E clearly state which group is being subtracted from which group. Also be mindful of the sign of the difference [+ or -])
SEM | (convert SD to SEM)
95% CI- Low
95% CI- High
Cost 2 | (cost in health care sector, cost of production loss, costs in other sectors, patient and family costs, total costs)
N evaluated
Cost 2 | (describe all, including method of calculation)
Cost 2, mean
Cost 2, SD | (convert SEM to SD)
Between group difference in cost per treatment | in column E clearly state which group is being subtracted from which group. Also be mindful of the sign of the difference [+ or -])
SEM | (convert SD to SEM)
95% CI- Low
95% CI- High
Cost 3 | (cost in health care sector, cost of production loss, costs in other sectors, patient and family costs, total costs)
N evaluated
Cost 3 | (describe all, including method of calculation)
Cost 3, mean
Cost 3, SD | (convert SEM to SD)
Between group difference in cost per treatment | in column E clearly state which group is being subtracted from which group. Also be mindful of the sign of the difference [+ or -])
SEM | (convert SD to SEM)
95% CI- Low
95% CI- High
Cost 4 | (cost in health care sector, cost of production loss, costs in other sectors, patient and family costs, total costs)
N evaluated
Cost 4 | (describe all, including method of calculation)
Cost 4, mean
Cost 4, SD | (convert SEM to SD)
Between group difference in cost per treatment | (in column E clearly state which group is being subtracted from which group. Also be mindful of the sign of the difference [+ or -])
SEM | (convert SD to SEM)
95% CI- Low
95% CI- High

Abbreviations: tx= treatment; SD = Standard Deviation, AE = Adverse Events, % = Percent SEM = Standard Error of the Mean

Harms Data

Data element | Comments, coding for data extraction
Ref id
First author, year
Intervention groups | (number each group 1-10)
Describe Adverse event
N evaluated
N with any Adverse event | At least one AE
Rate (%)
Rate ratio
Odds
Odds ratio
95% CI- Low
95% CI- High
P value
Withdrawal due to AE
Rate (%)
Rate ratio
Odds
Odds ratio
95% CI- Low
95% CI- High
Describe Serious Adverse Events
N of patients with serious AE
Rate (%)
Rate ratio
Odds
Odds ratio
95% CI- Low
95% CI- High
Specific AE
N of patients with specific AE
Risk/rate
Rate ratio
P value
Specific AE

Abbreviations: tx= treatment; SD = Standard Deviation, AE = Adverse Events, % = Percent SEM = Standard Error of the Mean