# Exact Search Strings

## Ovid MEDLINE(R) 1950 to February Week 1 2010

1 exp Neck/ or exp spine/ or exp back/ or Neck Muscles/ or Zygapophyseal Joint/
2 pain/ or pain, intractable/ or pain, referred/
3 (pain* or ache*).tw.
4 3 or 2
5 4 and 1
6 exp back pain/
7 exp back injuries/
8 (backpain* or backache*).tw.
9 exp spinal injuries/
10 exp spinal diseases/
11 ((disc* or disk*) adj3 (degener* or displace* or prolapse* or hernia* or bulge or protrusion* or extrusion* or sequestration* or disorder* or disease* or rupture* or slipped)).tw.
12 ((stenosis or stenoses) adj3 (lumbar or spine or spines or spinal)).tw.
13 (Spondylolys* or spondylolisthes* or Spondylisthes*).tw.
14 (Discitis or diskitis or Spondylodis*).tw.
15 (osteoporo* adj3 compression fracture*).tw.
16 vertebrogenic pain syndrome*.tw.
17 Sciatica/
18 (Sciatica or ischialgia).tw.
19 (Sciatic adj3 (Neuralgia or Bilateral)).tw.
20 Neck Pain/
21 (cervicalgia or Cervicodynia).tw.
22 ((anterior or posterior) adj3 (cervical pain or cervical ache*)).tw.
23 ((cervicogenic or cervico-genic) adj3 headache*).tw.
24 exp neck injuries/
25 (neckache* or neckpain*).tw.
26 (whiplash* or whip lash* or radiculomyelopath* or radiculo-myelopath*).tw.
27 (neck disorder* adj3 radicul*).tw.
28 (failed back or back surgery syndrome* or FBSS).tw.
29 ((Zygapophyseal or Facet or facets) adj3 (syndrome* or degenerat*)).tw.
30 ((back or neck or spine or spinal or lumbar* or thoracic) adj3 (ache* or aching or pain* or strain*)).tw.
31 (lumbago or dorsalgia).tw.
32 (myofascial adj3 (pain* or ache*)).tw.
33 or/5-32
34 Acupuncture/
35 Acupuncture Therapy/
36 Electroacupuncture/
37 (Acupuncture or acu-puncture or electroacupuncture or electro-acupuncture or electric acupuncture or electric acu-puncture or needling or acupressure or acupressure or mox?bustion).tw.
38 exp Manipulation, Spinal/
39 Manipulation, Chiropractic/
40 Chiropractic/
41 ((back or neck or spine or spinal or lumbar or cervical or chiropractic* or musculoskeletal* or musculo-skeletal*) adj3 (adjust* or manipulat* or mobiliz* or mobilis*)).tw.
42 (Manual adj therap*).tw.
43 (Manipulati* adj (therap* or medicine)).tw.
44 exp Massage/
45 (massag* or reflexolog* or rolfing or zone therap*).tw.
46 (Chih Ya or Shiatsu or Shiatzu or Zhi Ya).tw.
47 (Flexion adj2 distraction*).tw.
48 (myofascial adj3 (release or therap*)).tw.
49 Muscle energy technique*.tw.
50 Trigger point*.tw.
51 Proprioceptive Neuromuscular Facilitation*.tw.
52 Cyriax Friction.tw.
53 (Lomilomi or lomi-lomi or trager).tw.
54 Aston patterning.tw.
55 (Strain adj counterstrain).tw.
56 Alexander technique*.tw.
57 (Craniosacral Therap* or Cranio-sacral Therap*).tw.
58 (amma or ammo or Effleurage or Petrissage or hacking or Tapotment).tw.
59 Complementary Therapies/
60 ((complement* or alternat* or osteopathic*) adj (therap* or medicine)).tw.
61 (Tui Na or Tuina).tw.
62 or/34-61
63 33 and 62

The following filters were applied and overlap removed:

### Randomized/Controlled Clinical Trials

64 exp Randomized Controlled Trials as topic/
65 Randomized Controlled Trial.pt.
66 Controlled Clinical Trial.pt.
67 (random* or sham or placebo*).tw.
68 Placebos/
69 Random Allocation/
70 Single Blind Method/
71 Double Blind Method/
72 ((singl* or doubl* or tripl* or trebl*) adj (blind* or dumm* or mask*)).tw.
73 (RCT or RCTs).tw.
74 (control* adj2 (study or studies or trial*)).tw.
75 or/64-74
76 63 and 75
77 animal/
78 human/
79 77 not (77 and 78)
80 76 not 79

### Systematic Review

81 Meta-Analysis/
82 exp Meta-Analysis as Topic/
83 Meta analysis.pt.
84 (meta analy* or metaanaly* or met analy* or metanaly*).tw.
85 Review Literature as Topic/
86 (collaborative research or collaborative review* or collaborative overview*).tw.
87 (integrative research or integrative review* or integrative overview*).tw.
88 (quantitative adj3 (research or review* or overview*)).tw.
89 (research integration or research overview*).tw.
90 (systematic* adj3 (review* or overview*)).tw.
91 (methodologic* adj3 (review* or overview*)).tw.
92 exp Technology Assessment, Biomedical/
93 (hta or htas or technology assessment*).tw.
94 ((hand adj2 search*) or (manual* adj search*)).tw.
95 ((electronic adj database*) or (bibliographic* adj database*)).tw.
96 ((data adj2 abstract*) or (data adj2 extract*)).tw.
97 (Data adj3 (pool or pooled or pooling)).tw. (5850)
98 (Analys* adj3 (pool or pooled or pooling)).tw.
99 Mantel Haenszel.tw.
100 (Cochrane or PubMed or MEDLINE or EMBASE or PsycINFO or PsycLIT or PsychINFO or PsychLIT or CINAHL or Science Citation Index).ab.
101 or/81-100
102 63 and 101
103 102 not 79
104 103 not 80

### Safety

81 (ae or to or po or co).fs.
82 (safe or safety or unsafe).tw.
83 (side effect* or side event*).tw.
84 ((adverse or undesirable or harm* or injurious or serious or toxic) adj3 (effect* or reaction* or event* or incident* or outcome*)).tw.
85 (abnormalit* or toxicit* or complication* or consequence* or noxious or tolerabilit*).tw.
86 or/81-85
87 63 and 86
88 87 not 79
89 88 not 80

### Economics

90 economics/
91 exp “costs and cost analysis”/
92 Value of Life/
93 economics medical/
94 (econom* or cost or costs or costly or costing or price or prices or pricing).ti,ab.
95 (expenditure* not energy).ti,ab.
96 (value adj2 money).ti,ab.
97 budget.ti,ab.
98 or/90-97
99 63 and 98
100 99 not 79
101 100 not (80 or 89)

## EMBASE 1980 to 2010 Week 4

1 exp Neck/ or exp spine/ or exp back/ or Neck Muscle/ or Back Muscle/ or Zygapophyseal Joint/
2 Pain/ or Intractable Pain/ or Referred Pain/
3 (pain* or ache*).tw.
4 2 or 3
5 1 and 4
6 exp Backache/
7 (backache or backpain).tw.
8 exp Spine Injury/
9 exp Spine Disease/
10 ((disc* or disk*) adj3 (degener* or displace* or prolapse* or hernia* or bulge or protrusion* or extrusion* or sequestration* or disorder* or disease* or rupture* or slipped)).tw.
11 ((stenosis or stenoses) adj3 (lumbar or spine or spines or spinal)).tw.
12 (Spondylolys* or spondylolisthes* or Spondylisthes*).tw.
13 (Discitis or diskitis or Spondylodis*).tw.
14 (osteoporo* adj3 compression fracture*).tw.
15 vertebrogenic pain syndrome*.tw.
16 Ischialgia/
17 (Ischialgia or sciatica).tw.
18 (Sciatic adj3 (Neuralgia or Bilateral)).tw.
19 Neck Pain/
20 (cervicalgia or Cervicodynia).tw.
21 ((anterior or posterior) adj3 (cervical pain or cervical ache*)).tw.
22 ((cervicogenic or cervico-genic) adj3 headache*).tw.
23 exp neck injuries/
24 (neckache* or neckpain*).tw.
25 (whiplash* or whip lash* or radiculomyelopath* or radiculo-myelopath*).tw.
26 (failed back or back surgery syndrome* or FBSS).tw.
27 (myofascial adj3 (pain* or ache*)).tw.
28 ((Zygapophyseal or Facet or facets) adj3 (syndrome* or degenerat*)).tw.
29 ((back or neck or spine or spinal or lumbar* or thoracic) adj3 (ache* or aching or pain* or strain*)).tw.
30 (lumbago or dorsalgia).tw.
31 (neck disorder* adj3 radicul*).tw.
32 or/5-31
33 exp Acupuncture/
34 Electroacupuncture/
35 (Acupuncture or acu-puncture or electroacupuncture or electro-acupuncture or electric* acupuncture or electric* acu-puncture or needling or acupressure or acupressure or mox?bustion).tw.
36 exp Manipulative Medicine/
37 chiropractic/
38 ((back or neck or spine or spinal or lumbar or cervical or chiropractic* or musculoskeletal* or musculo-skeletal*) adj3 (adjust* or manipulat* or mobiliz* or mobilis*)).tw.
39 (Manual adj therap*).tw.
40 (Manipulati* adj (therap* or medicine)).tw.
41 Massage/
42 (massag* or reflexolog* or rolfing or zone therap*).tw.
43 (Chih Ya or Shiatsu or Shiatzu or Zhi Ya).tw.
44 (Flexion adj2 distraction*).tw.
45 (myofascial adj3 (release or therap*)).tw.
46 Muscle energy technique*.tw.
47 Trigger point*.tw.
48 Proprioceptive Neuromuscular Facilitation*.tw.
49 Cyriax Friction.tw.
50 (Lomilomi or lomi-lomi or trager).tw.
51 Aston patterning.tw.
52 (Strain adj counterstrain).tw.
53 Alexander technique*.tw.
54 (Craniosacral Therap* or Cranio-sacral Therap*).tw.
55 (amma or ammo or Effleurage or Petrissage or hacking or Tapotment).tw.
56 Alternative Medicine/
57 ((complement* or alternat* or osteopathic*) adj (therap* or medicine)).tw.
58 (Tui Na or Tuina).tw.
59 or/33-58
60 32 and 59

The following filters were applied and overlap removed:

### Randomized/Controlled Clinical Trials

61 Randomized Controlled Trial/
62 exp Controlled Clinical Trial/
63 (random* or sham or placebo*).tw.
64 Placebo/
65 Randomization/
66 Single Blind Procedure/
67 Double Blind Procedure/
68 ((singl* or doubl* or tripl* or trebl*) adj (blind* or dumm* or mask*)).tw.
69 (RCT or RCTs).tw.
70 (control* adj2 (study or studies or trial*)).tw.
71 or/61-70
72 60 and 71
73 human.sh.
74 nonhuman. sh.
75 animal.sh.
76 animal experiment.sh.
77 or/74-76
78 77 not (73 and 77)
79 72 not 78

### Systematic Review

80 Meta Analysis/ (34242)
81 “systematic review”/ (24457)
82 (meta analy* or metaanaly* or met analy* or metanaly*).tw. (22067)
83 (collaborative research or collaborative review* or collaborative overview*).tw. (834)
84 (integrative research or integrative review* or integrative overview*).tw. (128)
85 (quantitative adj3 (research or review* or overview*)).tw. (1551)
86 (research integration or research overview*).tw. (59)
87 (systematic* adj3 (review* or overview*)).tw. (17008)
88 (methodologic* adj3 (review* or overview*)).tw. (1013)
89 biomedical technology assessment/ (5472)
90 (hta or htas or technology assessment*).tw. (1902)
91 ((hand adj2 search*) or (manual* adj search*)).tw. (2396)
92 ((electronic adj database*) or (bibliographic* adj database*)).tw. (2660)
93 ((data adj2 abstract*) or (data adj2 extract*)).tw. (11462)
94 (Data adj3 (pool or pooled or pooling)).tw. (4432)
95 (Analys* adj3 (pool or pooled or pooling)).tw. (3135)
96 Mantel Haenszel.tw. (1463)
97 (Cochrane or PubMed or MEDLINE or EMBASE or PsycINFO or PsycLIT or PsychINFO or PsychLIT or CINAHL or Science Citation Index).ab. (28709)
98 or/80-97 (100019)
99 60 and 98 (421)
100 99 not 78 (421)
101 100 not 79 (178)

### Safety

80 (ae or co or si or to).fs.
81 (safe or safety or unsafe).tw.
82 (side effect* or side event*).tw.
83 ((adverse or undesirable or harm* or injurious or serious or toxic) adj3 (effect* or reaction* or event* or incident* or outcome*)).tw.
84 (abnormalit* or toxicit* or complication* or consequence* or noxious or tolerabilit*).tw.
85 or/80-84
86 60 and 85
87 86 not 78
88 87 not 79

### Economics

89 health-economics/
90 exp economic-evaluation/
91 exp health-care-cost/
92 (econom* or cost or costs or costly or costing or price or prices or pricing).ti,ab.
93 (expenditure* not energy).ti,ab.
94 (value adj2 money).ti,ab.
95 budget*.ti,ab.
96 socioeconomics/
97 or/89-96
98 60 and 97
99 98 not 78
100 99 not (79 or 88)

## AMED <1985 to January 2010>

1 exp Neck/ or exp spine/ or exp back/ or Neck Muscles/
2 pain/ or pain intractable/
3 (pain* or ache*).tw.
4 2 or 3
5 1 and 4
6 exp backache/
7 back injuries/
8 (backache* or backpain*).tw.
9 spinal injuries/
10 exp spinal disease/
11 ((disc* or disk*) adj3 (degener* or displace* or prolapse* or hernia* or bulge or protrusion* or extrusion* or sequestration* or disorder* or disease* or rupture* or slipped)).tw.
12 ((stenosis or stenoses) adj3 (lumbar or spine or spines or spinal)).tw.
13 (Spondylolys* or spondylolisthes* or Spondylisthes*).tw.
14 (Discitis or diskitis or Spondylodis*).tw.
15 (osteoporo* adj3 compression fracture*).tw.
16 vertebrogenic pain syndrome*.tw.
17 sciatica/
18 (Sciatica or Ischialgia).tw.
19 (Sciatic adj3 (Neuralgia or Bilateral)).tw.
20 neck pain/
21 (cervicalgia or Cervicodynia).tw.
22 ((anterior or posterior) adj3 (cervical pain or cervical ache*)).tw.
23 ((cervicogenic or cervico-genic) adj3 headache*).tw.
24 exp neck injuries/
25 (neckache* or neckpain*).tw.
26 (neck disorder* adj3 radicul*).tw.
27 (whiplash* or whip lash* or radiculomyelopath* or radiculo-myelopath*).tw.
28 (failed back or back surgery syndrome*).tw.
29 FBSS.tw.
30 ((Zygapophyseal or Facet or facets) adj3 (syndrome* or degenerat*)).tw.
31 ((back or neck or spine or spinal or lumbar* or thoracic) adj3 (ache* or aching or pain* or strain*)).tw.
32 (lumbago or dorsalgia).tw.
33 (myofascial adj3 (pain* or ache*)).tw.
34 or/5-33
35 exp acupuncture/
36 exp acupuncture therapy/
37 (Acupuncture or acu-puncture or electroacupuncture or electro-acupuncture or electric acupuncture or electric acu-puncture or needling or acupressure or acupressure or mox?bustion).tw.
38 spinal manipulation/
39 exp manipulation chiropractic/
40 chiropractic/
41 ((back or neck or spine or spinal or lumbar or cervical or chiropractic* or musculoskeletal* or musculo-skeletal*) adj3 (adjust* or manipulat* or mobiliz* or mobilis*)).tw.
42 (Manual adj therap*).tw.
43 (Manipulati* adj (therap* or medicine)).tw.
44 massage/
45 (massag* or reflexolog* or rolfing or zone therap*).tw.
46 (Chih Ya or Shiatsu or Shiatzu or Zhi Ya).tw.
47 (Flexion adj2 distraction*).tw.
48 (myofascial adj3 (release or therap*)).tw.
49 Muscle energy technique*.tw.
50 Trigger point*.tw.
51 Proprioceptive Neuromuscular Facilitation*.tw.
52 Cyriax Friction.tw.
53 (Lomilomi or lomi-lomi or trager or Tui Na or Tuina).tw.
54 Aston patterning.tw.
55 (Strain adj counterstrain).tw.
56 Alexander technique*.tw.
57 (Craniosacral Therap* or Cranio-sacral Therap*).tw.
58 (amma or ammo or Effleurage or Petrissage or hacking or Tapotment).tw.
59 complementary therapies/
60 ((complement* or alternat* or osteopathic*) adj (therap* or medicine)).tw.
61 or/35-60
62 34 and 61

The following filters were applied and overlap removed:

### Randomized/Controlled Clinical Trials

63 randomized controlled trials/
64 randomized controlled trial.pt.
65 controlled clinical trial.pt.
66 (random* or sham or placebo*).tw.
67 Placebos/
68 double blind method/ or random allocation/
69 ((singl* or doubl* or tripl* or trebl*) adj (blind* or dumm* or mask*)).tw.
70 (RCT or RCTs).tw.
71 (control* adj2 (study or studies or trial*)).tw.
72 randomised controlled trial.pt.
73 or/63-72
74 62 and 73

### Systematic Review

75 meta analysis/
76 meta analysis.pt.
77 (meta analy* or metaanaly* or met analy* or metanaly*).tw.
78 (collaborative research or collaborative review* or collaborative overview*).tw.
79 (integrative research or integrative review* or integrative overview*).tw.
80 (quantitative adj3 (research or review* or overview*)).tw.
81 (research integration or research overview*).tw.
82 (systematic* adj3 (review* or overview*)).tw.
83 (methodologic* adj3 (review* or overview*)).tw.
84 (hta or htas or technology assessment*).tw.
85 ((hand adj2 search*) or (manual* adj search*)).tw.
86 ((electronic adj database*) or (bibliographic* adj database*)).tw.
87 ((data adj2 abstract*) or (data adj2 extract*)).tw.
88 (Data adj3 (pool or pooled or pooling)).tw.
89 (Analys* adj3 (pool or pooled or pooling)).tw.
90 Mantel Haenszel.tw.
91 (Cochrane or PubMed or MEDLINE or EMBASE or PsycINFO or PsycLIT or PsychINFO or PsychLIT or CINAHL or Science Citation Index).ab.
92 or/75-91 (2843)
93 62 and 92 (150)
94 93 not 74

### Safety

75 (safe or safety or unsafe).tw.
76 (side effect* or side event*).tw.
77 ((adverse or undesirable or harm* or injurious or serious or toxic) adj3 (effect* or reaction* or event* or incident* or outcome*)).tw.
78 (abnormalit* or toxicit* or complication* or consequence* or noxious or tolerabilit*).tw.
79 adverse effects/
80 or/75-79
81 62 and 80
82 81 not 74

### Economics

84 Economics/
85 exp “costs and cost analysis”/ or patient satisfaction/ or “quality of life”/
86 (econom* or cost or costs or costly or costing or price or prices or pricing or budget*).ti,ab.
87 (expenditure* not energy).ti,ab.
88 (value adj2 money).ti,ab.
89 (QOL or QOLY or QOLYs or HRQOL or QALY or QALYs).ti,ab.
90 or/84-89
91 62 and 90
92 91 not (74 or 82)

## ACP Journal Club <1991 to August 2008>

1 (backpain* or backache*).tw.
2 ((disc* or disk*) adj3 (degener* or displace* or prolapse* or hernia* or bulge or protrusion* or extrusion* or sequestration* or disorder* or disease* or rupture* or slipped)).tw.
3 ((stenosis or stenoses) adj3 (lumbar or spine or spines or spinal)).tw.
4 (Spondylolys* or spondylolisthes* or Spondylisthes*).tw.
5 (Discitis or diskitis or Spondylodis*).tw.
6 (osteoporo* adj3 compression fracture*).tw.
7 vertebrogenic pain syndrome*.tw.
8 (Sciatica or ischialgia).tw.
9 (Sciatic adj3 (Neuralgia or Bilateral)).tw.
10 (cervicalgia or Cervicodynia).tw.
11 ((anterior or posterior) adj3 (cervical pain or cervical ache*)).tw.
12 ((cervicogenic or cervico-genic) adj3 headache*).tw.
13 (neckache* or neckpain*).tw.
14 (whiplash* or whip lash* or radiculomyelopath* or radiculo-myelopath*).tw.
15 (failed back or back surgery syndrome* or FBSS).tw.
16 ((Zygapophyseal or Facet or facets) adj3 (syndrome* or degenerat*)).tw.
17 ((back or neck or spine or spinal or lumbar* or thoracic) adj3 (ache* or aching or pain* or strain*)).tw.
18 (lumbago or dorsalgia).tw.
19 (myofascial adj3 (pain* or ache*)).tw.
20 (neck disorder* adj3 radicul*).tw.
21 or/1-20
22 (Acupuncture or acu-puncture or electroacupuncture or electro-acupuncture or electric acupuncture or electric acu-puncture or needling or acupressure or acupressure or mox?bustion).tw.
23 ((back or neck or spine or spinal or lumbar or cervical or chiropractic* or musculoskeletal* or musculo-skeletal*) adj3 (adjust* or manipulat* or mobiliz* or mobilis*)).tw.
24 (Manual adj therap*).tw.
25 (Manipulati* adj (therap* or medicine)).tw.
26 (massag* or reflexolog* or rolfing or zone therap*).tw.
27 (Chih Ya or Shiatsu or Shiatzu or Zhi Ya).tw.
28 (Flexion adj2 distraction*).tw.
29 (myofascial adj3 (release or therap*)).tw.
30 Muscle energy technique*.tw.
31 Trigger point*.tw.
32 Proprioceptive Neuromuscular Facilitation*.tw.
33 Cyriax Friction.tw.
34 (Lomilomi or lomi-lomi or trager or Tui Na or Tuina).tw.
35 Aston patterning.tw.
36 (Strain adj counterstrain).tw.
37 Alexander technique*.tw.
38 (Craniosacral Therap* or Cranio-sacral Therap*).tw.
39 (amma or ammo or Effleurage or Petrissage or hacking or Tapotment).tw.
40 ((complement* or alternat* or osteopathic*) adj (therap* or medicine)).tw.
41 or/22-40
42 21 and 41

## CINAHL <1982 to September Week 3 2008>

1 Neck/
2 Back/
3 exp Spine/
4 Neck Muscles/
5 or/1-4
6 pain/
7 Referred Pain/
8 (pain* or ache*).tw.
9 or/6-8
10 5 and 9
11 exp Back Pain/
12 exp Back Injuries/
13 (backache* or backpain*).tw.
14 exp Spinal Injuries/
15 exp Spinal Diseases/
16 ((disc* or disk*) adj3 (degener* or displace* or prolapse* or hernia* or bulge or protrusion* or extrusion* or sequestration* or disorder* or disease* or rupture* or slipped)).tw.
17 ((stenosis or stenoses) adj3 (lumbar or spine or spines or spinal)).tw.
18 (Spondylolys* or spondylolisthes* or Spondylisthes*).tw.
19 (Discitis or diskitis or Spondylodis*).tw.
20 (osteoporo* adj3 compression fracture*).tw.
21 vertebrogenic pain syndrome*.tw.
22 Sciatica/
23 (Sciatica or Ischialgia).tw.
24 (Sciatic adj3 (Neuralgia or Bilateral)).tw.
25 Neck Pain/
26 (cervicalgia or Cervicodynia).tw.
27 ((anterior or posterior) adj3 (cervical pain* or cervical ache*)).tw.
28 ((cervicogenic or cervico-genic) adj3 headache*).tw.
29 exp Neck Injuries/
30 (neckache* or neckpain*).tw.
31 (whiplash* or whip lash*).tw.
32 (failed back or back surgery syndrome* or FBSS).tw.
33 (neck disorder* adj3 radicul*).tw.
34 ((Zygapophyseal or Facet or facets) adj3 (syndrome* or degenerat*)).tw.
35 ((back or neck or spine or spinal or lumbar* or thoracic) adj3 (ache* or aching or pain* or strain*)).tw.
36 (lumbago or dorsalgia).tw.
37 (myofascial adj3 (pain* or ache*)).tw.
38 or/10-37
39 exp Acupuncture/
40 (Acupuncture or acu-puncture or electroacupuncture or electro-acupuncture or electric* acupuncture or electric* acu-puncture or acupressure or acu-pressure or mox?bustion).tw.
41 exp chiropractic/ or manipulation, chiropractic/
42 ((back or neck or spine or spinal or lumbar or cervical or chiropractic* or musculoskeletal* or musculo-skeletal*) adj3 (adjust* or manipulat* or mobiliz* or mobilis*)).tw.
43 (Manual adj therap*).tw.
44 (Manipulati* adj (therap* or medicine)).tw.
45 exp Massage/
46 (massag* or reflexolog* or rolfing or zone therap*).tw.
47 (Chih Ya or Shiatsu or Shiatzu or Zhi Ya or Tui Na).tw.
48 (Flexion adj2 distraction*).tw.
49 (myofascial adj3 (release or therap*)).tw.
50 Muscle energy technique*.tw.
51 Trigger point*.tw.
52 Proprioceptive Neuromuscular Facilitation*.tw.
53 Cyriax Friction.tw.
54 (Lomilomi or lomi-lomi or trager or Tui Na or Tuina).tw.
55 Aston patterning.tw.
56 (Strain adj counterstrain).tw.
57 Alexander technique*.tw.
58 (Craniosacral Therap* or Cranio-sacral Therap*).tw.
59 (amma or ammo or Effleurage or Petrissage or hacking or Tapotment).tw.
60 Alternative Therapies/
61 ((complement* or alternat* or osteopathic*) adj (therap* or medicine)).tw.
62 or/39-61
63 38 and 62

The following filters were applied and overlap removed:

### Randomized/Controlled Clinical Trials

64 exp Clinical Trials/
65 clinical trial.pt.
66 (random* or sham or placebo*).tw.
67 Placebos/
68 Random Assignment/
69 ((singl* or doubl* or tripl* or trebl*) adj (blind* or dumm* or mask*)).tw.
70 (RCT or RCTs).tw.
71 (control* adj2 (study or studies or trial*)).tw.
72 or/64-71
73 63 and 72

### Systematic Review

74 systematic review.pt.
75 Meta Analysis/
76 (meta analy* or metaanaly* or met analy* or metanaly*).tw.
77 (collaborative research or collaborative review* or collaborative overview*).tw.
78 (integrative research or integrative review* or integrative overview*).tw.
79 (quantitative adj3 (research or review* or overview*)).tw.
80 (integrative research or research integration or research overview*).tw.
81 (systematic* adj3 (review* or overview*)).tw.
82 (methodologic* adj3 (review* or overview*)).tw.
83 (hta or htas or technology assessment*).tw.
84 ((hand adj2 search*) or (manual* adj2 search*)).tw.
85 ((electronic adj database*) or (bibliographic* adj database*)).tw.
86 ((data adj2 abstract*) or (data adj2 extract*)).tw.
87 (data adj3 (pool or pooled or pooling)).tw.
88 (analys* adj3 (pool or pooled or pooling)).tw.
89 Mantel Haenszel.tw.
90 (Cochrane or PubMed or MEDLINE or EMBASE or PsycINFO or PsycLIT or PsychINFO or PsychLIT or CINAHL or Science Citation Index).ab.
91 or/74-90
92 63 and 91
93 92 not 73

### Safety

74 (safe or safety or unsafe).tw.
75 (side effect* or side event*).tw.
76 ((adverse or undesirable or harm* or injurious or serious or toxic) adj3 (effect* or reaction* or event* or incident* or outcome*)).tw.
77 (abnormalit* or toxicit* or complication* or consequence* or noxious or tolerabilit*).tw.
78 (ae or po or co).fs.
79 or/74-78
80 63 and 79
81 80 not 73

### Economics

84 exp economics/ (258163)
85 exp financial management/ (17991)
86 exp financial support/ (168377)
87 exp “financing organized”/ (51967)
88 exp “business”/ (26100)
89 or/85-88 (249186)
90 84 not 89 (24912)
91 health resource allocation/ (3423)
92 health resource utilization/ (4982)
93 exp “Quality of Life”/ (23733)
94 Patient Satisfaction/ (14059)
95 (econom* or cost or costs or costly or costing or price or prices or pricing or budget*).ti,ab. (53804)
96 (expenditure* not energy).ti,ab. (2243)
97 (value adj2 money).ti,ab. (187)
98 (QOL or QOLY or QOLYs or HRQOL or QALY or QALYs).ti,ab. (3012)
99 or/90-98 (107583)
100 63 and 99 (255)
101 100 not (73 or 81)

## MANTIS <1880 to October 2008>

1 neck.de.
2 (spine or Cervical Vertebrae or Coccyx or Intervertebral Disk or Lumbar Vertebrae or Sacrum or Spinal Canal or Thoracic Vertebrae).de.
3 (Back or Lumbosacral Region or Sacrococcygeal Region).de.
4 neck muscles.de.
5 Zygapophyseal Joint.de.
6 or/1-5
7 pain.de.
8 pain, intractable.de.
9 pain, referred.de.
10 (pain* or ache* or aching).tw.
11 or/7-10
12 6 and 11
13 (back pain or low back pain). de.
14 back injuries.de.
15 (backpain* or backache*).tw.
16 (spinal injuries or spinal fractures).de.
17 (spinal diseases or Intervertebral Disk Displacement or Spinal Stenosis or Spondylolisthesis or Spondylolysis).de.
18 ((disc* or disk*) adj3 (degener* or displace* or prolapse* or hernia* or bulge or protrusion* or extrusion* or sequestration* or disorder* or disease* or rupture* or slipped)).tw.
19 ((stenosis or stenoses) adj3 (lumbar or spine or spines or spinal)).tw.
20 (Spondylolys* or spondylolisthes* or Spondylisthes*).tw.
21 (Discitis or diskitis or Spondylodis*).tw.
22 (osteoporo* adj3 compression fracture*).tw.
23 vertebrogenic pain syndrome*.tw.
24 Sciatica.de.
25 (Sciatica or ischialgia).tw.
26 (Sciatic adj3 (Neuralgia or Bilateral)).tw.
27 neck pain. de.
28 (cervicalgia or Cervicodynia).tw.
29 ((anterior or posterior) adj3 (cervical pain or cervical ache*)).tw.
30 ((cervicogenic or cervico-genic) adj3 headache*).tw.
31 (neck injuries or Whiplash Injuries).de.
32 (neckache* or neckpain*).tw.
33 (whiplash* or whip lash* or radiculomyelopath* or radiculo-myelopath*).tw.
34 (neck disorder* adj3 radicul*).tw.
35 failed back surgery. de.
36 (failed back or back surgery syndrome* or FBSS).tw.
37 facet syndrome.de.
38 ((Zygapophyseal or Facet or facets) adj3 (syndrome* or degenerat*)).tw.
39 ((back or neck or spine or spinal or lumbar* or thoracic) adj3 (ache* or aching or pain* or strain*)).tw.
40 (lumbago or dorsalgia).tw.
41 (myofascial pain syndromes or myofascial).de.
42 (myofascial adj3 (pain* or ache*)).tw.
43 or/12-42
44 Acupuncture.de.
45 Acupuncture Therapy.de.
46 electroacupuncture.de.
47 (Acupuncture or acu-puncture or electroacupuncture or electro-acupuncture or electric acupuncture or electric acu-puncture or needling or acupressure or acupressure or mox?bustion).tw.
48 Manipulation, Spinal.de.
49 Manipulation, Chiropractic.de.
50 Chiropractic. de.
51 ((back or neck or spine or spinal or lumbar or cervical or chiropractic* or musculoskeletal* or musculo-skeletal*) adj3 (adjust* or manipulat* or mobiliz* or mobilis*)).tw.
52 (Manual adj therap*).tw.
53 (Manipulati* adj (therap* or medicine)).tw.
54 (Massage or Acupressure).de.
55 (massag* or reflexolog* or rolfing or zone therap*).tw.
56 (Chih Ya or Shiatsu or Shiatzu or Zhi Ya).tw.
57 (Flexion adj2 distraction*).tw.
58 (myofascial adj3 (release or therap*)).tw.
59 Muscle energy technique*.tw.
60 Trigger point*.tw.
61 Proprioceptive Neuromuscular Facilitation*.tw.
62 Cyriax Friction.tw.
63 (Lomilomi or lomi-lomi or trager).tw.
64 Aston patterning.tw.
65 (Strain adj counterstrain).tw.
66 Alexander technique*.tw.
67 (Craniosacral Therap* or Cranio-sacral Therap*).tw.
68 (amma or ammo or Effleurage or Petrissage or hacking or Tapotment).tw.
69 Complementary Therapies.de.
70 ((complement* or alternat* or osteopathic*) adj (therap* or medicine)).tw.
71 (Tui Na or Tuina).tw.
72 or/44-71
73 43 and 72

The following filters were applied and overlap removed:

### Randomized/Controlled Clinical Trials

74 (Randomized Controlled Trial or Randomized Controlled Trials).de.
75 (Controlled Clinical Trial or Controlled Clinical Trials).de.
76 (random* or sham or placebo*).tw.
77 Placebos.de.
78 Random Allocation.de.
79 Single Blind Method.de.
80 Double Blind Method.de.
81 ((singl* or doubl* or tripl* or trebl*) adj (blind* or dumm* or mask*)).tw.
82 (RCT or RCTs).tw.
83 (control* adj2 (study or studies or trial*)).tw.
84 or/74-83
85 animal.de.
86 human.de.
87 85 not (85 and 86)
88 73 and 84
89 88 not 87

### Systematic Review

90 Meta-Analysis.de.
91 (meta analy* or metaanaly* or met analy* or metanaly*).tw.
92 (collaborative research or collaborative review* or collaborative overview*).tw.
93 (integrative research or integrative review* or integrative overview*).tw.
94 (quantitative adj3 (research or review* or overview*)).tw.
95 (research integration or research overview*).tw.
96 (systematic* adj3 (review* or overview*)).tw.
97 (methodologic* adj3 (review* or overview*)).tw.
98 Technology Assessment, Biomedical.de.
99 (hta or htas or technology assessment*).tw.
100 ((hand adj2 search*) or (manual* adj search*)).tw.
101 ((electronic adj database*) or (bibliographic* adj database*)).tw.
102 ((data adj2 abstract*) or (data adj2 extract*)).tw.
103 (Data adj3 (pool or pooled or pooling)).tw.
104 (Analys* adj3 (pool or pooled or pooling)).tw.
105 Mantel Haenszel.tw.
106 (Cochrane or PubMed or MEDLINE or EMBASE or PsycINFO or PsycLIT or PsychINFO or PsychLIT or CINAHL or Science Citation Index).ab.
107 or/90-106
108 73 and 107
109 108 not 87
110 109 not 89

### Safety

90 (safe or safety or unsafe).tw.
91 (side effect* or side event*).tw.
92 ((adverse or undesirable or harm* or injurious or serious or toxic) adj3 (effect* or reaction* or event* or incident* or outcome*)).tw.
93 (abnormalit* or toxicit* or complication* or consequence* or noxious or tolerabilit*).tw.
94 adverse effects.de.
95 complications.de.
96 toxicity.de.
97 or/90-96
98 73 and 97
99 98 not 87
100 99 not 89

### Economics

101 economics.de.
102 “costs and cost analysis”.de.
103 “value of life”.de.
104 economics, medical.de.
105 (econom* or cost or costs or costly or costing or price or prices or pricing).ti,ab.
106 (expenditure* not energy).ti,ab.
107 (value adj2 money).ti,ab.
108 budget.ti,ab.
109 cost benefit analysis.de.
110 or/101-109
111 73 and 110
112 111 not 87
113 112 not (89 or 100)

## Cochrane Library 2010 Issue 1

### Systematic Review and RCT/CCT

1 MeSH descriptor Neck explode all trees
2 MeSH descriptor Spine explode all trees
3 MeSH descriptor Back explode all trees
4 MeSH descriptor Neck Muscles explode all trees
5 MeSH descriptor Zygapophyseal Joint explode all trees
6 MeSH descriptor Pain explode all trees
7 MeSH descriptor Pain, Intractable explode all trees
8 MeSH descriptor Pain, Referred explode all trees
9 (pain* or ache*):ti,ab,kw
10 (1 OR 2 OR 3 OR 4 OR 5)
11 (6 OR 7 OR 8 OR 9)
12 (10 AND 11)
13 MeSH descriptor Back Pain explode all trees
14 MeSH descriptor Back Injuries explode all trees
15 (backpain* or backache*):ti,ab,kw
16 MeSH descriptor Spinal Injuries explode all trees
17 MeSH descriptor Spinal Diseases explode all trees
18 (disc* or disk*) NEAR/3 (degener* or displace* or prolapse* or hernia* or bulge or protrusion* or extrusion* or sequestration* or disorder* or disease* or rupture* or slipped):ti,ab,kw
19 (stenosis or stenoses) NEAR/3 (lumbar or spine or spines or spinal):ti,ab,kw
20 (Spondylolys* or spondylolisthes* or Spondylisthes*):ti,ab,kw or (Discitis or diskitis or Spondylodis*):ti,ab,kw
21 (osteoporo* NEAR/3 compression fracture*):ti,ab,kw
22 (vertebrogenic pain syndrome*):ti,ab,kw
23 MeSH descriptor Sciatica explode all trees
24 (Sciatica or ischialgia):ti,ab,kw or (Sciatic NEAR/3 (Neuralgia or Bilateral)):ti,ab,kw
25 MeSH descriptor Neck Pain explode all trees
26 (cervicalgia or Cervicodynia):ti,ab,kw or (anterior or posterior) NEAR/3 (cervical pain or cervical ache*):ti,ab,kw or (cervicogenic or cervico-genic) NEAR/3 headache*:ti,ab,kw
27 MeSH descriptor Neck Injuries explode all trees
28 (neckache* or neckpain*):ti,ab,kw or (whiplash* or whip lash* or radiculomyelopath* or radiculo-myelopath*):ti,ab,kw or (failed back or back surgery syndrome* OR FBSS):ti,ab,kw or (lumbago or dorsalgia):ti,ab,kw
29 (neck disorder*) NEAR/3 radicul*:ti,ab,kw or (Zygapophyseal or Facet or facets) NEAR/3 (syndrome* or degenerat*):ti,ab,kw or (back or neck or spine or spinal or lumbar* or thoracic) NEAR/3 (ache* or aching or pain* or strain*):ti,ab,kw or (myofascial adj3 (pain* or ache*)):ti,ab,kw
30 (12 OR 13 OR 14 OR 15 OR 16 OR 17 OR 18 OR 19 OR 20 OR 21 OR 22 OR 23 OR 24 OR 25 OR 26 OR 27 OR 28 OR 29)
31 MeSH descriptor Acupuncture explode all trees
32 MeSH descriptor Acupuncture Therapy explode all trees
33 MeSH descriptor Electroacupuncture explode all trees
34 (acupuncture or electric acupuncture or electric acu-puncture or needling or acupressure or acu-pressure or mox?bustion):ti,ab,kw
35 MeSH descriptor Manipulation, Spinal explode all trees
36 MeSH descriptor Manipulation, Chiropractic explode all trees
37 MeSH descriptor Chiropractic explode all trees
38 (back or neck or spine or spinal or lumbar or cervical or chiropractic* or musculoskeletal* or musculo-skeletal*) NEAR/3 (adjust* or manipulat* or mobiliz* or mobilis*):ti,ab,kw or (Manual NEXT therap*):ti,ab,kw or (Manipulati* NEXT (therap* or medicine)):ti,ab,kw
39 MeSH descriptor Massage explode all trees
40 (massag* or reflexolog* or rolfing or zone therap*):ti,ab,kw or (Chih Ya or Shiatsu or Shiatzu or Zhi Ya):ti,ab,kw or (Flexion NEAR/2 distraction*):ti,ab,kw or (myofascial NEAR/3 (release or therap*)):ti,ab,kw or (Muscle energy technique*):ti,ab,kw
41 (Trigger point*):ti,ab,kw or (Proprioceptive Neuromuscular Facilitation*):ti,ab,kw or (Cyriax Friction):ti,ab,kw or (Lomilomi or lomi-lomi or trager or Tui Na or Tuina):ti,ab,kw or (Aston patterning):ti,ab,kw
42 (Strain NEAR/1 counterstrain):ti,ab,kw or (Alexander technique*):ti,ab,kw or (Craniosacral Therap* or Cranio-sacral Therap*):ti,ab,kw or (amma or ammo or Effleurage or Petrissage or hacking or Tapotment):ti,ab,kw or (complement* or alternat* or osteopathic*) NEXT (therap* or medicine):ti,ab,kw
43 MeSH descriptor Complementary Therapies, this term only
44 (31 OR 32 OR 33 OR 34 OR 35 OR 36 OR 37 OR 38 OR 39 OR 40 OR 41 OR 42 OR 43)
45 (30 AND 44)

### Safety

46 Any MeSH descriptor with qualifier: AE
47 Any MeSH descriptor with qualifier: TO
48 Any MeSH descriptor with qualifier: PO
49 Any MeSH descriptor with qualifier: CO
50 (safe or safety or unsafe):ti,ab,kw or (side effect* or side event*):ti,ab,kw or (adverse or undesirable or harm* or injurious or serious or toxic) NEAR/3 (effect* or reaction* or event* or incident* or outcome*):ti,ab,kw or (abnormalit* or toxicit* or complication* or consequence* or noxious or tolerabilit*):ti,ab,kw
51 (46 OR 47 OR 48 OR 49 OR 50)
52 (45 AND 51)

### Economics

53 MeSH descriptor Economics, this term only
54 MeSH descriptor Economics, Medical, this term only
55 MeSH descriptor Costs and Cost Analysis explode all trees
56 MeSH descriptor Value of Life explode all trees
57 MeSH descriptor Quality-Adjusted Life Years explode all trees
58 MeSH descriptor Patient Satisfaction explode all trees
59 Any MeSH descriptor with qualifier: EC
60 (econom* or cost or costs or costly or costing or price or prices or pricing or budget*):ti,ab,kw or (expenditure* not energy):ti,ab,kw or (value NEAR/2 money):ti,ab,kw or (QOL or QOLY or QOLYs or HRQOL or QALY or QALYs):ti,ab,kw
61 (53 OR 54 OR 55 OR 56 OR 57 OR 58 OR 59 OR 60)
62 (45 AND 61)
63 (62 AND NOT 52)

## Index to Chiropractic Literature 2008 Oct 10

S1 Subject:: “BACK PAIN” OR “BACK INJURIES” OR “NECK INJURIES” OR “NECK PAIN” OR “SPINAL DISEASES” OR “SPINAL INJURIES” OR “SCIATICA” OR All Fields:backpain* or backache* OR “back pain” OR “back ache” OR “back pains” OR “back aches” OR neck pain* OR neck ache* OR “neck pain” OR neck ache” OR “neck pains” OR “neck aches” OR All Fields:Spondylolys* or Spondylolisthes* or Spondylisthes* or Discitis or Diskitis or Spondylod* OR Sciatica OR Ischialgia* OR Cervicalgia OR Cervicodynia
S2 All Fields:whiplash* or “whip lash” OR “whip lashes” or radiculomyelopath* or “radiculo-myelopathy” OR “radiculo-myelopathies” OR All Fields:“failed back” or “back surgery syndrome” or “back surgery syndromes” or FBSS OR All Fields:lumbago or dorsalgia or “myofascial pain” OR “myofascial ache”
S3 All Fields: “cervical pain” OR “cervical ache” OR “vertebrogenic pain syndrome” OR “vertebrogenic pain syndromes” OR All Fields:“degenerated disk” OR “degenerative disk” OR “degenerated disks” OR “degenerative disks” OR All Fields:“degenerated disc” OR “degenerative disc OR “degenerated discs” OR “degenerative discs”
S4 All Fields:“prolapsed disk” OR “prolapsed disks” OR “prolapsed disc” OR “prolapsed discs” OR “disk prolapse” OR “disc prolapse” “herniated disk” OR “herniated disks” OR “herniated disc” OR “herniated discs” OR All Fields:“displaced disk” OR “displaced disks” OR “displaced disc” OR “displaced discs” OR “osteoporotic compression fracture” OR “osteoporotic compression fractures” OR All Fields::“lumbar stenosis” OR “lumbar stenoses” OR “spinal stenosis” OR “spinal stenoses” OR “cervicogenic headache” OR “cervicogenic headaches” OR “cervico-genic headache” OR “cervico-genic headaches”
S5 All Fields:radiculomyelopathy OR radiculomyelopathies OR “radiculomyelopathy” OR “radiculo-myelopathies” OR All Fields:“Zygapophyseal joint syndrome” OR “Zygapophyseal joint syndromes” OR “Z-joint syndrome” OR “Z-joint syndromes” OR “facet joint syndrome” OR “facet joint syndromes” OR All Fields:“thoracic pain” OR “thoracic ache” OR “spinal pain” OR “spinal ache” OR “lumbar pain” OR “lumbar ache”
S6 S1 OR S2 OR S3 OR S4 OR S5
S7 Subject:“ACUPUNCTURE” OR “ACUPRESSURE” OR “ACUPUNCTURE THERAPY” OR “ELECTROACUPUNCTURE” OR “MANIPULATION, LUMBAR” OR “MANIPULATION, CERVICAL” OR “MANIPULATION, CHIROPRACTIC” OR “MANIPULATION, SPINAL” OR “MANIPULATION, THORACIC” OR Subject:“MASSAGE” OR “CHIROPRACTIC” OR All Fields: acupuncture or “acu-puncture” or electroacupuncture or “electro-acupuncture” or “electric acupuncture” or “electric acu-puncture” or needling or acupressure or “acu-pressure” or moxibustion or moxabustion
S8 All Fields:“manual therapy” OR “manual therapies” OR massage* or reflexology* or rolfing or “zone therapy” or “zone therapies” OR All Fields:“Chih Ya” or Shiatsu or Shiatzu or “Zhi Ya” or “Flexion distraction” OR “Trigger point” OR “Trigger points” OR “Proprioceptive Neuromuscular Facilitation” OR “Proprioceptive Neuromuscular Facilitations” OR All Fields:“myofascial release” or “myofascial therapy” OR “myofascial therapies” OR “Muscle energy technique” OR “Muscle energy techniques” OR “Cyriax Friction”
S9 All Fields:: Lomilomi or “lomi-lomi” or trager or “Aston patterning” or “Strain counter strain” or “Alexander technique” or “Alexander techniques” or “Toy Na” or Tuna OR All Fields:Craniosacral Therapy” or “Craniosacral Therapies” or “Cranio-sacral Therapy”or “Cranio-sacral Therapies” or amma or ammo or Effleurage or Petrissage or hacking or Tapotment OR All Fields:manipulat* or mobiliz* or mobilis*
S10 All Fields:“complementary therapy” OR “complementary therapies” OR “complementary medicine” OR All Fields:“alternative therapy” OR “alternative therapies” OR “alternative medicine” OR All Fields:“osteopathic therapy” OR “osteopathic therapies” OR “osteopathic medicine”
S11 S7 OR S8 OR S9 OR S10
S12 S6 AND S11

### Randomized/Controlled Clinical Trials

S13 , Publication Type:Randomized Controlled Trial
S14 Subject:“RANDOMIZED CONTROLLED TRIALS AS TOPIC” OR “CONTROLLED CLINICAL TRIALS” OR “PLACEBOS” OR All Fields:random* or sham or placebo* or RCT or RCTs or CCT or CCTs OR All Fields:“controlled clinical trial” or “controlled clinical trials” or “controlled study” or “controlled studies” or “control study” or “controlled studies”
S15 S12 AND S14
S16 S13 OR S15

### Safety

S17 All Fields:safe or safety or unsafe or “side effect” or “side effects” or “side event” or “side events” OR All Fields:abnormalit* or toxicit* or complication* or consequence* or noxious or tolerabilit* OR All Fields:adverse or undesirable or harm* or injurious or serious or toxic
S18 S12 AND S17

### Economics

S19 Subject:“ECONOMICS” OR “ECONOMICS, MEDICAL” OR “COSTS AND COST ANALYSIS” OR All Fields:econom* or cost or costs or costly or costing or price or prices or pricing or budget* or expenditure or value or money
S20 S12 AND S19

## LILACS 2008 Oct 13

( ( ( ( ( “BACK PAIN” or “NECK PAIN” ) or “SPINAL DISEASES” ) or “BACK INJURIES” ) or “SPINAL INJURIES” ) or “NECK INJURIES” ) or “SCIATICA” [Descritor de assunto] and acupuncture or electroacupuncture or acupressure or massage or manipulation or chiropractic or osteopathic [Palavras]

## Acubriefs 2008 Oct 10

KW: Back pain + SPECIALTY: RCT/randomized controlled trials

KW: neck pain + SPECIALTY: RCT/randomized controlled trials

KW: thoracic pain + SPECIALTY: RCT/randomized controlled trials

KW: spinal diseases + SPECIALTY: RCT/randomized controlled trials

KW: lumbago + SPECIALTY: RCT/randomized controlled trials

KW: facet joint + SPECIALTY: RCT/randomized controlled trials

Excluded PubMed refs, ACP Jnl Club, Cochrane, ClinicalTrials.gov, animal studies