# Acknowledgments

The University of Ottawa Evidence-based Practice Center thanks Katja Boehm, Manchun Fang, and Keiko Asakawa, for their assistance with data extraction of the foreign language studies. We would also like to thank Sepideh Ghorbani and Nisha Hazra for their assistance with data extraction, and the building of summary and evidence tables. Administrative support of this project was possible with help from Chantelle Garritty, Jodi Peters, and Bev MacLaren. We thank them for their continuing assistance.