# References

1 Alzheimer’s Association. 2009 Alzheimer’s disease facts and figures. Alzheimer’s & Dementia. 2009;5(3):234-70.
2 Brookmeyer R, Gray S, Kawas C. Projections of Alzheimer’s disease in the United States and the public health impact of delaying disease onset. Am J Public Health. 1998;88(9):1337-42. [pmid: 9736873].
3 Plassman BL, Langa KM, Fisher GG, et al. Prevalence of dementia in the United States: the aging, demographics, and memory study. Neuroepidemiology. 2007;29(1–2):125-32. [pmid: 17975326].
4 Hebert LE, Scherr PA, Bienias JL, et al. Alzheimer disease in the US population: prevalence estimates using the 2000 census. Arch Neurol. 2003;60(8):1119-22. [pmid: 12925369].
5 Alzheimer’s Disease International. World Alzheimer Report 2009. Available at :http://www.alz.co.uk/research/files/World%20Alzheimer%20Report.pdf. Accessed on September 30, 2009. 2009.
6 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders, Third Edition-Revised. Washington, DC. American Psychiatric Association. 1987.
7 McKhann G, Drachman D, Folstein M, et al. Clinical diagnosis of Alzheimer’s disease: report of the NINCDS-ADRDA Work Group under the auspices of Department of Health and Human Services Task Force on Alzheimer’s Disease. Neurology. 1984;34(7):939-44. [pmid: 6610841].
8 World Health Organization. International statistical classification of diseases and related health problems. Tenth Edition. Geneva. World Health Organization. 1992. Chapter V, categories F00-99, Mental behavioural and developmental disorders, clinical description and diagnostic guidelines.
9 American Psychiatric Association. Dignostic and Statistical Manual of Mental Disorders. Fourth Edition. Washington, DC. American Psychiatric Association. 1994.
10 Duyckaerts C, Delatour B, Potier MC, et al. Classification and basic pathology of Alzheimer disease. Acta Neuropathol (Berl). 2009;118(1):5-36. [pmid: 19381658].
11 Plassman BL, Langa KM, Fisher GG, et al. Prevalence of cognitive impairment without dementia in the United States.[summary for patients in Ann Intern Med. 2008 Mar 18;148(6):I-53; PMID: 18347348]. Ann Intern Med. 2008;148(6):427-34. [pmid: 18347351].
12 Petersen RC, Smith GE, Waring SC, et al. Mild cognitive impairment: clinical characterization and outcome.[erratum appears in Arch Neurol 1999 Jun;56(6):760]. Arch Neurol. 1999;56(3):303-8. [pmid: 10190820].
13 Bynum JP, Rabins PV, Weller W, et al. The relationship between a dementia diagnosis, chronic illness, medicare expenditures, and hospital use. J Am Geriatr Soc. 2004;52(2):187-94. [pmid: 14728626].
14 Eaker ED, Vierkant RA, Mickel SF, et al. Predictors of nursing home admission and/or death in incident Alzheimer’s disease and other dementia cases compared to controls: a population-based study. J Clin Epidemiol. 2002;55(5):462-8. [pmid: 12007549].
15 Evans DA, Smith LA, Scherr PA, et al. Risk of death from Alzheimer’s disease in a community population of older persons. Am J Epidemiol. 1991;134(4):403-12. [pmid: 1877601].
16 Helmer C, Joly P, Letenneur L, et al. Mortality with dementia: results from a French prospective community-based cohort. Am J Epidemiol. 2001;154(7):642-8. [pmid: 11581098].
17 Schulz R, O’Brien AT, Bookwala J, et al. Psychiatric and physical morbidity effects of dementia caregiving: prevalence, correlates, and causes. Gerontologist. 1995;35(6):771-91. [pmid: 8557205].
18 Moore MJ, Zhu CW, Clipp EC. Informal costs of dementia care: estimates from the National Longitudinal Caregiver Study. Journals of Gerontology Series B-Psychological Sciences & Social Sciences. 2001;56(4):S219-28.
19 Heron M, Hoyert D, Xu J, et al. Deaths: Preliminary data for 2006. National vital statistics reports. Hyattsville, MD. National Center for Health Statistics. 2008;56(16).
20 Braak H, Braak E. Frequency of stages of Alzheimer-related lesions in different age categories. Neurobiol Aging. 1997;18(4):351-7. [pmid: 9330961].
21 Launer LJ, Brock DB. Population-based studies of AD: message and methods: an epidemiologic view. Stat Med. 2004;23(2):191-7. [pmid: 14716721].
22 Irie F, Masaki KH, Petrovitch H, et al. Apolipoprotein E epsilon4 allele genotype and the effect of depressive symptoms on the risk of dementia in men: the Honolulu-Asia Aging Study. Arch Gen Psychiatry. 2008;65(8):906-12. [pmid: 18678795].
23 Wilson RS, Barnes LL, Bennett DA, et al. Proneness to psychological distress and risk of Alzheimer disease in a biracial community. Neurology. 2005;64(2):380-2. [pmid: 15668449].
24 Agency for Healthcare Research and Quality. Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews, Version 1.0 [Draft posted Oct. 2007]. Rockville, MD. Agency for Healthcare Research and Quality. Available at: http://effectivehealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf. Accessed September 3, 2009.
25 Wang C, Chung M, Balk E, et al. Effects of Omega-3 Fatty Acids on Cardiovascular Disease. Evidence Report/Technology Assessment No. 94 (Prepared by Tufts-New England Medical Center Evidence-based Practice Center, under Contract No. 290-02-0022). AHRQ Publication No. 04-E 009-2. Rockville, MD. Agency for Healthcare Research and Quality. March. 2004. Available at: http://www.ahrq.gov/downloads/pub/evidence/pdf/o3cardio/o3cardio.pdf. Accessed May 8, 2009.
26 Myers E, McCrory D, Mills A, et al. Effectiveness of Assisted Reproductive Technology. Evidence Report/Technology Assessment No. 167 (Prepared by the Duke University Evidence-based Practice Center under Contract No. 290-02-0025.) AHRQ Publication No. 08-E012. Rockville, MD. Agency for Healthcare Research and Quality. May. 2008. Available at: http://www.ahrq.gov/downloads/pub/evidence/pdf/infertility/infertility.pdf. Accessed May 8, 2009.
27 Juni P, Witschi A, Bloch R, et al. The hazards of scoring the quality of clinical trials for meta-analysis. JAMA. 1999;282(11):1054-60. [pmid: 10493204].
28 Egger M, Schneider M, Davey Smith G. Spurious precision? Meta-analysis of observational studies. BMJ. 1998;316(7125):140-4. [pmid: 9462324].
29 Fotuhi M, Mohassel P, Yaffe K, et al. Fish consumption, long-chain omega-3 fatty acids and risk of cognitive decline or Alzheimer disease: a complex association. Nature Clinical Practice Neurology. 2009;5(3):140-52.
30 Issa AM, Mojica WA, Morton SC, et al. The efficacy of omega-3 fatty acids on cognitive function in aging and dementia: a systematic review. Dement Geriatr Cogn Disord. 2006;21(2):88-96. [pmid: 16340205].
31 Lim WS, Gammack JK, Van Niekerk J, et al. Omega 3 fatty acid for the prevention of dementia. Cochrane Database of Systematic Reviews. 2006;(1). Art. No.: CD005379. [doi: 10.1002/14651858.CD005379.pub2].
32 Balk E, Chung M, Raman G, et al. B Vitamins and Berries and Age-Related Neurodegenerative Disorders. Evidence Report/Technology Assessment No. 134. (Prepared by Tufts-New England Medical Center Evidence-based Practice Center under Contract No. 290-02-0022). AHRQ Publication No. 06-E008. Rockville, MD. Agency for Healthcare Research and Quality. April. 2006. Available at: http://www.ahrq.gov/downloads/pub/evidence/pdf/berry/berry.pdf. Accessed September 18, 2009. 2006.
33 McGuinness B, Craig D, Bullock R, et al. Statins for the prevention of dementia. Cochrane Database of Systematic Reviews. 2009;(2). Art, No.: CD003160. [doi: 10.1002/14651858.CD003160.pub2].
34 McGuinness B, Todd S, Passmore P, et al. Blood pressure lowering in patients without prior cerebrovascular disease for prevention of cognitive impairment and dementia (Review). Cochrane Database of Systematic Reviews. 2006(2):CD004034.
35 Szekely CA, Thorne JE, Zandi PP, et al. Nonsteroidal anti-inflammatory drugs for the prevention of Alzheimer’s disease: a systematic review. Neuroepidemiology. 2004;23(4):159-69. [pmid: 15279021].
36 Grimley Evans J, Malouf R, Huppert F, et al. Dehydroepiandrosterone (DHEA) supplementation for cognitive function in healthy elderly people. Cochrane Database of Systematic Reviews. 2006(4):CD006221.
37 Lethaby A, Hogervorst E, Richards M, et al. Hormone replacement therapy for cognitive function in postmenopausal women.[update of Cochrane Database Syst Rev. 2002;(3):CD003122; PMID: 12137675]. Cochrane Database of Systematic Reviews. 2008(1):CD003122.
38 LeBlanc ES, Janowsky J, Chan BK, et al. Hormone replacement therapy and cognition: systematic review and meta-analysis. JAMA. 2001;285(11):1489-99. [pmid: 11255426].
39 Nickelsen T, Lufkin EG, Riggs BL, et al. Raloxifene hydrochloride, a selective estrogen receptor modulator: safety assessment of effects on cognitive function and mood in postmenopausal women. Psychoneuroendocrinology. 1999;24(1):115-28. [pmid: 10098223].
40 Anstey KJ, Lipnicki DM, Low L-F. Cholesterol as a risk factor for dementia and cognitive decline: a systematic review of prospective studies with meta-analysis. Am J Geriatr Psychiatry. 2008;16(5):343-54. [pmid: 18448847].
41 Biessels GJ, Staekenborg S, Brunner E, et al. Risk of dementia in diabetes mellitus: a systematic review.[erratum appears in Lancet Neurol. 2006 Feb;5(2):113]. Lancet Neurology. 2006;5(1):64-74. [pmid: 16361024].
42 Lu FP, Lin KP, Kuo HK, et al. Diabetes and the risk of multi-system aging phenotypes: a systematic review and meta-analysis. PLoS ONE [Electronic Resource]. 2009;4(1):e4144.
43 Cukierman T, Gerstein HC, Williamson JD. Cognitive decline and dementia in diabetes--systematic overview of prospective observational studies. Diabetologia. 2005;48(12):2460-9. [pmid: 16283246].
44 Raschetti R, Albanese E, Vanacore N, et al. Cholinesterase inhibitors in mild cognitive impairment: a systematic review of randomised trials. PLoS Medicine/Public Library of Science. 2007;4(11):e338.
45 Ownby RL, Crocco E, Acevedo A, et al. Depression and risk for Alzheimer disease: systematic review, meta-analysis, and metaregression analysis. Arch Gen Psychiatry. 2006;63(5):530-8. [pmid: 16651510].
46 Fleminger S, Oliver DL, Lovestone S, et al. Head injury as a risk factor for Alzheimer’s disease: the evidence 10 years on; a partial replication. J Neurol Neurosurg Psychiatry. 2003;74(7):857-62. [pmid: 12810767].
47 Beydoun MA, Beydoun HA, Wang Y. Obesity and central obesity as risk factors for incident dementia and its subtypes: a systematic review and meta-analysis. Obes Rev. 2008;9(3):204-18. [pmid: 18331422].
48 Angevaren M, Aufdemkampe G, Verhaar HJJ, et al. Physical activity and enhanced fitness to improve cognitive function in older people without known cognitive impairment.[update of Cochrane Database Syst Rev. 2008;(2):CD005381; PMID: 18425918]. Cochrane Database of Systematic Reviews. 2008(3):CD005381.
49 Caamano-Isorna F, Corral M, Montes-Martinez A, et al. Education and dementia: a meta-analytic study. Neuroepidemiology. 2006;26(4):226-32. [pmid: 16707907].
50 Anstey KJ, von Sanden C, Salim A, et al. Smoking as a risk factor for dementia and cognitive decline: a meta-analysis of prospective studies. Am J Epidemiol. 2007;166(4):367-78. [pmid: 17573335].
51 Anstey KJPD, Mack HAPD, Cherbuin NPD. Alcohol consumption as a risk factor for dementia and cognitive decline: meta-analysis of prospective studies. Am J Geriatr Psychiatry. 2009;17(7):542-555. [pmid: 19546653].
52 Santibanez M, Bolumar F, Garcia AM, et al. Occupational risk factors in Alzheimer’s disease: a review assessing the quality of published epidemiological studies. Occup Environ Med. 2007;64(11):723-32. [pmid: 17525096].
53 Bertram L, McQueen MB, Mullin K, et al. Systematic meta-analyses of Alzheimer disease genetic association studies: the AlzGene database. Nat Genet. 2007;39(1):17-23. [pmid: 17192785].
54 Luchsinger JA, Tang MX, Miller J, et al. Relation of higher folate intake to lower risk of Alzheimer disease in the elderly. Arch Neurol. 2007;64(1):86-92. [pmid: 17210813].
55 Morris MC, Evans DA, Schneider JA, et al. Dietary folate and vitamins B-12 and B-6 not associated with incident Alzheimer’s disease. J Alzheimers Dis. 2006;9(4):435-43. [pmid: 16917153].
56 Morris MC, Evans DA, Bienias JL, et al. Dietary niacin and the risk of incident Alzheimer’s disease and of cognitive decline. J Neurol Neurosurg Psychiatry. 2004;75(8):1093-9. [pmid: 15258207].
57 Ravaglia G, Forti P, Maioli F, et al. Homocysteine and folate as risk factors for dementia and Alzheimer disease. Am J Clin Nutr. 2005;82(3):636-43. [pmid: 16155278].
58 Wang HX, Wahlin A, Basun H, et al. Vitamin B(12) and folate in relation to the development of Alzheimer’s disease. Neurology. 2001;56(9):1188-94. [pmid: 11342684].
59 Morris MC, Tangney CC, Bienias JL, et al. Validity and reproducibility of a food frequency questionnaire by cognition in an older biracial sample. Am J Epidemiol. 2003;158(12):1213-7. [pmid: 14652307].
60 Engelhart MJ, Geerlings MI, Ruitenberg A, et al. Dietary intake of antioxidants and risk of Alzheimer disease. JAMA. 2002;287(24):3223-9. [pmid: 12076218].
61 Commenges D, Scotet V, Renaud S, et al. Intake of flavonoids and risk of dementia. Eur J Epidemiol. 2000;16(4):357-63. [pmid: 10959944].
62 Fillenbaum GG, Kuchibhatla MN, Hanlon JT, et al. Dementia and Alzheimer’s disease in community-dwelling elders taking vitamin C and/or vitamin E. Ann Pharmacother. 2005;39(12):2009-14. [pmid: 16227448].
63 Gray SL, Anderson ML, Crane PK, et al. Antioxidant vitamin supplement use and risk of dementia or Alzheimer’s disease in older adults. J Am Geriatr Soc. 2008;56(2):291-5. [pmid: 18047492].
64 Laurin D, Masaki KH, Foley DJ, et al. Midlife dietary intake of antioxidants and risk of late-life incident dementia: the Honolulu-Asia Aging Study. Am J Epidemiol. 2004;159(10):959-67. [pmid: 15128608].
65 Luchsinger JA, Tang MX, Shea S, et al. Antioxidant vitamin intake and risk of Alzheimer disease. Arch Neurol. 2003;60(2):203-8. [pmid: 12580704].
66 Masaki KH, Losonczy KG, Izmirlian G, et al. Association of vitamin E and C supplement use with cognitive function and dementia in elderly men. Neurology. 2000;54(6):1265-72. [pmid: 10746596].
67 Maxwell CJ, Hicks MS, Hogan DB, et al. Supplemental use of antioxidant vitamins and subsequent risk of cognitive decline and dementia. Dement Geriatr Cogn Disord. 2005;20(1):45-51. [pmid: 15832036].
68 Morris MC, Beckett LA, Scherr PA, et al. Vitamin E and vitamin C supplement use and risk of incident Alzheimer disease. Alzheimer Dis Assoc Disord. 1998;12(3):121-6. [pmid: 9772012].
69 Morris MC, Evans DA, Bienias JL, et al. Dietary intake of antioxidant nutrients and the risk of incident Alzheimer disease in a biracial community study. JAMA. 2002;287(24):3230-7. [pmid: 12076219].
70 Morris MC, Evans DA, Tangney CC, et al. Relation of the tocopherol forms to incident Alzheimer disease and to cognitive change. Am J Clin Nutr. 2005;81(2):508-14. [pmid: 15699242].
71 Zandi PP, Anthony JC, Khachaturian AS, et al. Reduced risk of Alzheimer disease in users of antioxidant vitamin supplements: the Cache County Study. Arch Neurol. 2004;61(1):82-8. [pmid: 14732624].
72 Kalmijn S, Launer LJ, Ott A, et al. Dietary fat intake and the risk of incident dementia in the Rotterdam Study. Ann Neurol. 1997;42(5):776-82. [pmid: 9392577].
73 Barberger-Gateau P, Letenneur L, Deschamps V, et al. Fish, meat, and risk of dementia: cohort study. BMJ. 2002;325(7370):932-3. [pmid: 12399342].
74 Laurin D, Verreault R, Lindsay J, et al. Omega-3 fatty acids and risk of cognitive impairment and dementia. J Alzheimers Dis. 2003;5(4):315-22. [pmid: 14624027].
75 Morris MC, Evans DA, Bienias JL, et al. Consumption of fish and n-3 fatty acids and risk of incident Alzheimer disease. Arch Neurol. 2003;60(7):940-6. [pmid: 12873849].
76 Huang TL, Zandi PP, Tucker KL, et al. Benefits of fatty fish on dementia risk are stronger for those without APOE epsilon4. Neurology. 2005;65(9):1409-14. [pmid: 16275829].
77 Schaefer EJ, Bongard V, Beiser AS, et al. Plasma phosphatidylcholine docosahexaenoic acid content and risk of dementia and Alzheimer disease: the Framingham Heart Study. Arch Neurol. 2006;63(11):1545-50. [pmid: 17101822].
78 Barberger-Gateau P, Raffaitin C, Letenneur L, et al. Dietary patterns and risk of dementia: the Three-City cohort study. Neurology. 2007;69(20):1921-30. [pmid: 17998483].
79 Samieri C, Feart C, Letenneur L, et al. Low plasma eicosapentaenoic acid and depressive symptomatology are independent predictors of dementia risk. Am J Clin Nutr. 2008;88(3):714-21. [pmid: 18779288].
80 Devore EE, Grodstein F, van Rooij FJ, et al. Dietary intake of fish and omega-3 fatty acids in relation to long-term dementia risk. Am J Clin Nutr. 2009;90(1):170-6. [pmid: 19474131].
81 Kroger E, Verreault R, Carmichael PH, et al. Omega-3 fatty acids and risk of dementia: the Canadian Study of Health and Aging. Am J Clin Nutr. 2009;90(1):184-92. [pmid: 19474137].
82 Morris MC, Evans DA, Bienias JL, et al. Dietary fats and the risk of incident Alzheimer disease. Arch Neurol. 2003;60(2):194-200. [pmid: 12580703].
83 Laitinen MH, Ngandu T, Rovio S, et al. Fat intake at midlife and risk of dementia and Alzheimer’s disease: a population-based study. Dement Geriatr Cogn Disord. 2006;22(1):99-107. [pmid: 16710090].
84 Scarmeas N, Stern Y, Tang MX, et al. Mediterranean diet and risk for Alzheimer’s disease. Ann Neurol. 2006;59(6):912-21. [pmid: 16622828].
85 Scarmeas N, Luchsinger JA, Schupf N, et al. Physical activity, diet, and risk of Alzheimer disease. JAMA. 2009;302(6):627-37. [pmid: 19671904].
86 Scarmeas N, Stern Y, Mayeux R, et al. Mediterranean diet and mild cognitive impairment. Arch Neurol. 2009;66(2):216-25. [pmid: 19204158].
87 Feart C, Samieri C, Rondeau V, et al. Adherence to a Mediterranean diet, cognitive decline, and risk of dementia. JAMA. 2009;302(6):638-48. [pmid: 19671905].
88 Hughes TF, Andel R, Small BJ, et al. Midlife fruit and vegetable consumption and risk of dementia in later life in Swedish twins. Am J Geriatr Psychiatry. 2009. epub date 2009/11/17. [doi: 10.1097/JGP.0b013e3181c65250].
89 Dai Q, Borenstein AR, Wu Y, et al. Fruit and vegetable juices and Alzheimer’s disease: the Kame Project. Am J Med. 2006;119(9):751-9. [pmid: 16945610].
90 Luchsinger JA, Tang MX, Shea S, et al. Caloric intake and the risk of Alzheimer disease. Arch Neurol. 2002;59(8):1258-63. [pmid: 12164721].
91 Yamada M, Kasagi F, Sasaki H, et al. Association between dementia and midlife risk factors: the Radiation Effects Research Foundation Adult Health Study. J Am Geriatr Soc. 2003;51(3):410-4. [pmid: 12588587].
92 Curb JD, Rodriguez BL, Abbott RD, et al. Longitudinal association of vascular and Alzheimer’s dementias, diabetes, and glucose tolerance. Neurology. 1999;52(5):971-5. [pmid: 10102414].
93 Akomolafe A, Beiser A, Meigs JB, et al. Diabetes mellitus and risk of developing Alzheimer disease: results from the Framingham Study. Arch Neurol. 2006;63(11):1551-5. [pmid: 17101823].
94 Hayden KM, Zandi PP, Lyketsos CG, et al. Vascular risk factors for incident Alzheimer disease and vascular dementia: the Cache County study. Alzheimer Dis Assoc Disord. 2006;20(2):93-100. [pmid: 16772744].
95 Irie F, Fitzpatrick AL, Lopez OL, et al. Enhanced risk for Alzheimer disease in persons with type 2 diabetes and APOE epsilon4: the Cardiovascular Health Study Cognition Study. Arch Neurol. 2008;65(1):89-93. [pmid: 18195144].
96 Xu WL, von Strauss E, Qiu CX, et al. Uncontrolled diabetes increases the risk of Alzheimer’s disease: a population-based cohort study. Diabetologia. 2009;52(6):1031-9. [pmid: 19280172].
97 Kalmijn S, Foley D, White L, et al. Metabolic cardiovascular syndrome and risk of dementia in Japanese-American elderly men. The Honolulu-Asia aging study. Arterioscler Thromb Vasc Biol. 2000;20(10):2255-60. [pmid: 11031212].
98 Muller M, Tang MX, Schupf N, et al. Metabolic syndrome and dementia risk in a multiethnic elderly cohort. Dement Geriatr Cogn Disord. 2007;24(3):185-92. [pmid: 17641531].
99 Borenstein AR, Wu Y, Mortimer JA, et al. Developmental and vascular risk factors for Alzheimer’s disease. Neurobiol Aging. 2005;26(3):325-34. [pmid: 15639310].
100 Kivipelto M, Helkala EL, Laakso MP, et al. Midlife vascular risk factors and Alzheimer’s disease in later life: longitudinal, population based study. BMJ. 2001;322(7300):1447-51. [pmid: 11408299].
101 Kivipelto M, Ngandu T, Fratiglioni L, et al. Obesity and vascular risk factors at midlife and the risk of dementia and Alzheimer disease. Arch Neurol. 2005;62(10):1556-60. [pmid: 16216938].
102 Launer LJ, Ross GW, Petrovitch H, et al. Midlife blood pressure and dementia: the Honolulu-Asia aging study. Neurobiol Aging. 2000;21(1):49-55. [pmid: 10794848].
103 Li G, Rhew IC, Shofer JB, et al. Age-varying association between blood pressure and risk of dementia in those aged 65 and older: a community-based prospective cohort study. J Am Geriatr Soc. 2007;55(8):1161-7. [pmid: 17661953].
104 Lindsay J, Laurin D, Verreault R, et al. Risk factors for Alzheimer’s disease: a prospective analysis from the Canadian Study of Health and Aging. Am J Epidemiol. 2002;156(5):445-53. [pmid: 12196314].
105 Luchsinger JA, Reitz C, Honig LS, et al. Aggregation of vascular risk factors and risk of incident Alzheimer disease. Neurology. 2005;65(4):545-51. [pmid: 16116114].
106 Posner HB, Tang MX, Luchsinger J, et al. The relationship of hypertension in the elderly to AD, vascular dementia, and cognitive function. Neurology. 2002;58(8):1175-81. [pmid: 11971083].
107 Qiu C, Winblad B, Fastbom J, et al. Combined effects of APOE genotype, blood pressure, and antihypertensive drug use on incident AD. Neurology. 2003;61(5):655-60. [pmid: 12963757].
108 Shah RC, Wilson RS, Bienias JL, et al. Relation of blood pressure to risk of incident Alzheimer’s disease and change in global cognitive function in older persons. Neuroepidemiology. 2006;26(1):30-6. [pmid: 16254451].
109 Morris MC, Scherr PA, Hebert LE, et al. Association of incident Alzheimer disease and blood pressure measured from 13 years before to 2 years after diagnosis in a large community study. Arch Neurol. 2001;58(10):1640-6. [pmid: 11594923].
110 Freitag MH, Peila R, Masaki K, et al. Midlife pulse pressure and incidence of dementia: the Honolulu-Asia Aging Study. Stroke. 2006;37(1):33-7. [pmid: 16339468].
111 Tan ZS, Seshadri S, Beiser A, et al. Plasma total cholesterol level as a risk factor for Alzheimer disease: the Framingham Study. Arch Intern Med. 2003;163(9):1053-7. [pmid: 12742802].
112 Stewart R, White LR, Xue QL, et al. Twenty-six-year change in total cholesterol levels and incident dementia: the Honolulu-Asia Aging Study. Arch Neurol. 2007;64(1):103-7. [pmid: 17210816].
113 Kivipelto M, Helkala EL, Laakso MP, et al. Apolipoprotein E epsilon4 allele, elevated midlife total cholesterol level, and high midlife systolic blood pressure are independent risk factors for late-life Alzheimer disease.[summary for patients in Ann Intern Med. 2002 Aug 6;137(3):I-18; PMID: 12160384]. Ann Intern Med. 2002;137(3):149-55. [pmid: 12160362].
114 Notkola IL, Sulkava R, Pekkanen J, et al. Serum total cholesterol, apolipoprotein E epsilon 4 allele, and Alzheimer’s disease. Neuroepidemiology. 1998;17(1):14-20. [pmid: 9549720].
115 Li G, Shofer JB, Kukull WA, et al. Serum cholesterol and risk of Alzheimer disease: a community-based cohort study. Neurology. 2005;65(7):1045-50. [pmid: 16217057].
116 Reitz C, Tang M-X, Luchsinger J, et al. Relation of plasma lipids to Alzheimer disease and vascular dementia. Arch Neurol. 2004;61(5):705-14. [pmid: 15148148].
117 Slooter AJ, Cruts M, Ott A, et al. The effect of APOE on dementia is not through atherosclerosis: the Rotterdam Study. Neurology. 1999;53(7):1593-5. [pmid: 10534277].
118 Yoshitake T, Kiyohara Y, Kato I, et al. Incidence and risk factors of vascular dementia and Alzheimer’s disease in a defined elderly Japanese population: the Hisayama Study. Neurology. 1995;45(6):1161-8. [pmid: 7783883].
119 Seshadri S, Beiser A, Selhub J, et al. Plasma homocysteine as a risk factor for dementia and Alzheimer’s disease. N Engl J Med. 2002;346(7):476-83. [pmid: 11844848].
120 Luchsinger JA, Tang MX, Shea S, et al. Plasma homocysteine levels and risk of Alzheimer disease. Neurology. 2004;62(11):1972-6. [pmid: 15184599].
121 Blasko I, Jellinger K, Kemmler G, et al. Conversion from cognitive health to mild cognitive impairment and Alzheimer’s disease: prediction by plasma amyloid beta 42, medial temporal lobe atrophy and homocysteine. Neurobiol Aging. 2008;29(1):1-11. [pmid: 17055615].
122 Luchsinger JA, Patel B, Tang M-X, et al. Measures of adiposity and dementia risk in elderly persons. Arch Neurol. 2007;64(3):392-8. [pmid: 17353383].
123 Whitmer RA, Gunderson EP, Quesenberry CP Jr, et al. Body mass index in midlife and risk of Alzheimer disease and vascular dementia. Curr Alzheimer Res. 2007;4(2):103-9. [pmid: 17430231].
124 Atti AR, Palmer K, Volpato S, et al. Late-life body mass index and dementia incidence: nine-year follow-up data from the Kungsholmen Project. J Am Geriatr Soc. 2008;56(1):111-6. [pmid: 18028342].
125 Hughes TF, Borenstein AR, Schofield E, et al. Association between late-life body mass index and dementia: The Kame Project. Neurology. 2009;72(20):1741-6. [pmid: 19451529].
126 Fitzpatrick AL, Kuller LH, Lopez OL, et al. Midlife and late-life obesity and the risk of dementia: cardiovascular health study. Arch Neurol. 2009;66(3):336-42. [pmid: 19273752].
127 Graves AB, White E, Koepsell TD, et al. The association between head trauma and Alzheimer’s disease. Am J Epidemiol. 1990;131(3):491-501. [pmid: 2405648].
128 Rasmusson DX, Brandt J, Martin DB, et al. Head injury as a risk factor in Alzheimer’s disease. Brain Inj. 1995;9(3):213-9. [pmid: 7606235].
129 Broe GA, Henderson AS, Creasey H, et al. A case-control study of Alzheimer’s disease in Australia. Neurology. 1990;40(11):1698-707. [pmid: 2146525].
130 Amaducci LA, Fratiglioni L, Rocca WA, et al. Risk factors for clinically diagnosed Alzheimer’s disease: a case-control study of an Italian population. Neurology. 1986;36(7):922-31. [pmid: 3714054].
131 Chandra V, Kokmen E, Schoenberg BS, et al. Head trauma with loss of consciousness as a risk factor for Alzheimer’s disease. Neurology. 1989;39(12):1576-8. [pmid: 2586772].
132 Chandra V, Philipose V, Bell PA, et al. Case-control study of late onset "probable Alzheimer’s disease". Neurology. 1987;37(8):1295-300. [pmid: 3614650].
133 Forster DP, Newens AJ, Kay DW, et al. Risk factors in clinically diagnosed presenile dementia of the Alzheimer type: a case-control study in northern England. J Epidemiol Community Health. 1995;49(3):253-8. [pmid: 7629459].
134 Ferini-Strambi L, Smirne S, Garancini P, et al. Clinical and epidemiological aspects of Alzheimer’s disease with presenile onset: a case control study. Neuroepidemiology. 1990;9(1):39-49. [pmid: 2330070].
135 Fratiglioni L, Ahlbom A, Viitanen M, et al. Risk factors for late-onset Alzheimer’s disease: a population-based, case-control study. Ann Neurol. 1993;33(3):258-66. [pmid: 8498809].
136 Li G, Shen YC, Li YT, et al. A case-control study of Alzheimer’s disease in China. Neurology. 1992;42(8):1481-8. [pmid: 1641140].
137 The Canadian Study of Health and Aging: risk factors for Alzheimer’s disease in Canada. Neurology. 1994;44(11):2073-80. [pmid: 7969962].
138 Mortimer JA, French LR, Hutton JT, et al. Head injury as a risk factor for Alzheimer’s disease. Neurology. 1985;35(2):264-7. [pmid: 3969219].
139 O’Meara ES, Kukull WA, Sheppard L, et al. Head injury and risk of Alzheimer’s disease by apolipoprotein E genotype. Am J Epidemiol. 1997;146(5):373-84. [pmid: 9290497].
140 Tsolaki M, Fountoulakis K, Chantzi E, et al. Risk factors for clinically diagnosed Alzheimer’s disease: a case-control study of a Greek population. Int Psychogeriatr. 1997;9(3):327-41. [pmid: 9513031].
141 van Duijn CM, Tanja TA, Haaxma R, et al. Head trauma and the risk of Alzheimer’s disease. Am J Epidemiol. 1992;135(7):775-82. [pmid: 1595677].
142 Mehta KM, Ott A, Kalmijn S, et al. Head trauma and risk of dementia and Alzheimer’s disease: The Rotterdam Study. Neurology. 1999;53(9):1959-62. [pmid: 10599765].
143 Plassman BL, Havlik RJ, Steffens DC, et al. Documented head injury in early adulthood and risk of Alzheimer’s disease and other dementias. Neurology. 2000;55(8):1158-66. [pmid: 11071494].
144 Andersen K, Lolk A, Kragh-Sorensen P, et al. Depression and the risk of Alzheimer disease. Epidemiology. 2005;16(2):233-8. [pmid: 15703539].
145 Dal Forno G, Palermo MT, Donohue JE, et al. Depressive symptoms, sex, and risk for Alzheimer’s disease. Ann Neurol. 2005;57(3):381-7. [pmid: 15732103].
146 Li YS, Meyer JS, Thornby J. Longitudinal follow-up of depressive symptoms among normal versus cognitively impaired elderly. Int J Geriatr Psychiatry. 2001;16(7):718-27. [pmid: 11466752].
147 Palsson S, Aevarsson O, Skoog I. Depression, cerebral atrophy, cognitive performance and incidence of dementia. Population study of 85-year-olds. Br J Psychiatry. 1999;174:249-53. [pmid: 10448451].
148 Steffens DC, Welsh-Bohmer KA, Burke JR, et al. Methodology and preliminary results from the neurocognitive outcomes of depression in the elderly study. J Geriatr Psychiatry Neurol. 2004;17(4):202-11. [pmid: 15533991].
149 Lu PH, Edland SD, Teng E, et al. Donepezil delays progression to AD in MCI subjects with depressive symptoms. Neurology. 2009;72(24):2115-21. [pmid: 19528519].
150 Gatz JL, Tyas SL, St John P, et al. Do depressive symptoms predict Alzheimer’s disease and dementia?. J Gerontol A Biol Sci Med Sci. 2005;60(6):744-7. [pmid: 15983177].
151 Geerlings MI, den Heijer T, Koudstaal PJ, et al. History of depression, depressive symptoms, and medial temporal lobe atrophy and the risk of Alzheimer disease. Neurology. 2008;70(15):1258-64. [pmid: 18391157].
152 Luchsinger JA, Honig LS, Tang MX, et al. Depressive symptoms, vascular risk factors, and Alzheimer's disease. Int J Geriatr Psychiatry. 2008;23(9):922-8. [pmid: 18327871].
153 Arvanitakis Z, Schneider J, Wilson R, et al. Statins, incident Alzheimer disease, change in cognitive function, and neuropathology. Neurology. 2008;70(19 Pt 2):1795-802. [pmid: 18199831].
154 Haag M, Hofman A, Koudstaal P, et al. Statins are associated with a reduced risk of Alzheimer disease regardless of lipophilicity. The Rotterdam Study. J Neurol Neurosurg Psychiatry. 2009;80(1):13-7. [pmid: 18931004].
155 Li G, Higdon R, Kukull WA, et al. Statin therapy and risk of dementia in the elderly: a community-based prospective cohort study. Neurology. 2004;63(9):1624-8. [pmid: 15534246].
156 Li G, Larson E, Sonnen J, et al. Statin therapy is associated with reduced neuropathologic changes of Alzheimer disease. Neurology. 2007;69(9):878-85. [pmid: 17724290].
157 Rea T, Breitner J, Psaty B, et al. Statin use and the risk of incident dementia: the Cardiovascular Health Study. Arch Neurol. 2005;62(7):1047-51. [pmid: 16009757].
158 Zandi P, Sparks D, Khachaturian A, et al. Do statins reduce risk of incident dementia and Alzheimer disease? The Cache County Study. Arch Gen Psychiatry. 2005;62(2):217-24. [pmid: 15699299].
159 Sparks D, Kryscio R, Sabbagh M, et al. Reduced risk of incident AD with elective statin use in a clinical trial cohort. Curr Alzheimer Res. 2008;5(4):416-21. [pmid: 18690839].
160 Guo Z, Fratiglioni L, Viitanen M, et al. Apolipoprotein E genotypes and the incidence of Alzheimer's disease among persons aged 75 years and older: variation by use of antihypertensive medication?. Am J Epidemiol. 2001;153(3):225-31. [pmid: 11157409].
161 in't Veld BA, Ruitenberg A, Hofman A, et al. Antihypertensive drugs and incidence of dementia: the Rotterdam Study. Neurobiol Aging. 2001;22(3):407-12. [pmid: 11378246].
162 Khachaturian AS, Zandi PP, Lyketsos CG, et al. Antihypertensive medication use and incident Alzheimer disease: the Cache County Study. Arch Neurol. 2006;63(5):686-92. [pmid: 16533956].
163 Peila R, White LR, Masaki K, et al. Reducing the risk of dementia: efficacy of long-term treatment of hypertension. Stroke. 2006;37(5):1165-70. [pmid: 16601212].
164 Yasar S, Corrada M, Brookmeyer R, et al. Calcium channel blockers and risk of AD: the Baltimore Longitudinal Study of Aging. Neurobiol Aging. 2005;26(2):157-63. [pmid: 15582745].
165 Haag MD, Hofman A, Koudstaal PJ, et al. Duration of antihypertensive drug use and risk of dementia: A prospective cohort study. Neurology. 2009;72(20):1727-34. [pmid: 19228584].
166 Zandi PP, Anthony JC, Hayden KM, et al. Reduced incidence of AD with NSAID but not H2 receptor antagonists: the Cache County Study. Neurology. 2002;59(6):880-6. [pmid: 12297571].
167 in't Veld BA, Ruitenberg A, Hofman A, et al. Nonsteroidal antiinflammatory drugs and the risk of Alzheimer's disease. N Engl J Med. 2001;345(21):1515-21. [pmid: 11794217].
168 Stewart WF, Kawas C, Corrada M, et al. Risk of Alzheimer's disease and duration of NSAID use. Neurology. 1997;48(3):626-32. [pmid: 9065537].
169 Arvanitakis Z, Grodstein F, Bienias JL, et al. Relation of NSAIDs to incident AD, change in cognitive function, and AD pathology. Neurology. 2008;70(23):2219-25. [pmid: 18519870].
170 Cornelius C, Fastbom J, Winblad B, et al. Aspirin, NSAIDs, risk of dementia, and influence of the apolipoprotein E epsilon 4 allele in an elderly population. Neuroepidemiology. 2004;23(3):135-43. [pmid: 15084783].
171 Szekely CA, Breitner JC, Fitzpatrick AL, et al. NSAID use and dementia risk in the Cardiovascular Health Study: role of APOE and NSAID type. Neurology. 2008;70(1):17-24. [pmid: 18003940].
172 Breitner JC, Haneuse SJ, Walker R, et al. Risk of dementia and AD with prior exposure to NSAIDs in an elderly community-based cohort. Neurology. 2009;72(22):1899-905. [pmid: 19386997].
173 Wilson RS, Scherr PA, Hoganson G, et al. Early life socioeconomic status and late life risk of Alzheimer's disease. Neuroepidemiology. 2005;25(1):8-14. [pmid: 15855799].
174 Karp A, Kareholt I, Qiu C, et al. Relation of education and occupation-based socioeconomic status to incident Alzheimer's disease. Am J Epidemiol. 2004;159(2):175-83. [pmid: 14718220].
175 Letenneur L, Gilleron V, Commenges D, et al. Are sex and educational level independent predictors of dementia and Alzheimer's disease? Incidence data from the PAQUID project. J Neurol Neurosurg Psychiatry. 1999;66(2):177-83. [pmid: 10071096].
176 Stern Y, Gurland B, Tatemichi TK, et al. Influence of education and occupation on the incidence of Alzheimer's disease. JAMA. 1994;271(13):1004-10. [pmid: 8139057].
177 Cobb JL, Wolf PA, Au R, et al. The effect of education on the incidence of dementia and Alzheimer's disease in the Framingham Study. Neurology. 1995;45(9):1707-12. [pmid: 7675231].
178 Ott A, van Rossum CT, van Harskamp F, et al. Education and the incidence of dementia in a large population-based study: the Rotterdam Study. Neurology. 1999;52(3):663-6. [pmid: 10025813].
179 Scarmeas N, Levy G, Tang MX, et al. Influence of leisure activity on the incidence of Alzheimer's disease. Neurology. 2001;57(12):2236-42. [pmid: 11756603].
180 Kukull WA, Higdon R, Bowen JD, et al. Dementia and Alzheimer disease incidence: a prospective cohort study. Arch Neurol. 2002;59(11):1737-46. [pmid: 12433261].
181 Di Carlo A, Baldereschi M, Amaducci L, et al. Incidence of dementia, Alzheimer's disease, and vascular dementia in Italy. The ILSA Study. J Am Geriatr Soc. 2002;50(1):41-8. [pmid: 12028245].
182 Ngandu T, von Strauss E, Helkala EL, et al. Education and dementia: what lies behind the association?. Neurology. 2007;69(14):1442-50. [pmid: 17909157].
183 Tyas SL, Salazar JC, Snowdon DA, et al. Transitions to mild cognitive impairments, dementia, and death: findings from the Nun Study. Am J Epidemiol. 2007;165(11):1231-8. [pmid: 17431012].
184 Evans DA, Hebert LE, Beckett LA, et al. Education and other measures of socioeconomic status and risk of incident Alzheimer disease in a defined population of older persons. Arch Neurol. 1997;54(11):1399-405. [pmid: 9362989].
185 Helmer C, Letenneur L, Rouch I, et al. Occupation during life and risk of dementia in French elderly community residents. J Neurol Neurosurg Psychiatry. 2001;71(3):303-9. [pmid: 11511701].
186 Qiu C, Karp A, von Strauss E, et al. Lifetime principal occupation and risk of Alzheimer's disease in the Kungsholmen project. Am J Ind Med. 2003;43(2):204-11. [pmid: 12541276].
187 Helmer C, Damon D, Letenneur L, et al. Marital status and risk of Alzheimer's disease: a French population-based cohort study. Neurology. 1999;53(9):1953-8. [pmid: 10599764].
188 Wilson RS, Krueger KR, Arnold SE, et al. Loneliness and risk of Alzheimer disease. Arch Gen Psychiatry. 2007;64(2):234-40. [pmid: 17283291].
189 Fratiglioni L, Wang HX, Ericsson K, et al. Influence of social network on occurrence of dementia: a community-based longitudinal study. Lancet. 2000;355(9212):1315-9. [pmid: 10776744].
190 Hakansson K, Rovio S, Helkala EL, et al. Association between mid-life marital status and cognitive function in later life: population based cohort study. BMJ. 2009;339:b2462. [pmid: 19574312].
191 Saczynski JS, Pfeifer LA, Masaki K, et al. The effect of social engagement on incident dementia: the Honolulu-Asia Aging Study. Am J Epidemiol. 2006;163(5):433-40. [pmid: 16410348].
192 Wilson RS, Mendes De Leon CF, Barnes LL, et al. Participation in cognitively stimulating activities and risk of incident Alzheimer disease. JAMA. 2002;287(6):742-8. [pmid: 11851541].
193 Wilson RS, Scherr PA, Schneider JA, et al. Relation of cognitive activity to risk of developing Alzheimer disease. Neurology. 2007;69(20):1911-20. [pmid: 17596582].
194 Verghese J, Lipton RB, Katz MJ, et al. Leisure activities and the risk of dementia in the elderly. N Engl J Med. 2003;348(25):2508-16. [pmid: 12815136].
195 Akbaraly TN, Portet F, Fustinoni S, et al. Leisure activities and the risk of dementia in the elderly: results from the Three-City Study. Neurology. 2009;73(11):854-61. [pmid: 19752452].
196 Andel R, Crowe M, Pedersen NL, et al. Physical exercise at midlife and risk of dementia three decades later: a population-based study of Swedish twins. J Gerontol A Biol Sci Med Sci. 2008;63(1):62-6. [pmid: 18245762].
197 Abbott RD, White LR, Ross GW, et al. Walking and dementia in physically capable elderly men. JAMA. 2004;292(12):1447-53. [pmid: 15383515].
198 Larson EB, Wang L, Bowen JD, et al. Exercise is associated with reduced risk for incident dementia among persons 65 years of age and older. Ann Intern Med. 2006;144(2):73-81. [pmid: 16418406].
199 Laurin D, Verreault R, Lindsay J, et al. Physical activity and risk of cognitive impairment and dementia in elderly persons. Arch Neurol. 2001;58(3):498-504. [pmid: 11255456].
200 Rovio S, Kareholt I, Helkala EL, et al. Leisure-time physical activity at midlife and the risk of dementia and Alzheimer's disease. Lancet Neurol. 2005;4(11):705-11. [pmid: 16239176].
201 Rovio S, Kareholt I, Viitanen M, et al. Work-related physical activity and the risk of dementia and Alzheimer's disease. Int J Geriatr Psychiatry. 2007;22(9):874-82. [pmid: 17721898].
202 Podewils LJ, Guallar E, Kuller LH, et al. Physical activity, APOE genotype, and dementia risk: findings from the Cardiovascular Health Cognition Study. Am J Epidemiol. 2005;161(7):639-51. [pmid: 15781953].
203 Ravaglia G, Forti P, Lucicesare A, et al. Physical activity and dementia risk in the elderly: findings from a prospective Italian study. Neurology. 2008;70(19 Pt 2):1786-94. [pmid: 18094335].
204 Peters R, Poulter R, Warner J, et al. Smoking, dementia and cognitive decline in the elderly, a systematic review. BMC Geriatr. 2008;8:36. [pmid: 19105840].
205 Broe GA, Creasey H, Jorm AF, et al. Health habits and risk of cognitive impairment and dementia in old age: a prospective study on the effects of exercise, smoking and alcohol consumption. Aust N Z J Public Health. 1998;22(5):621-3. [pmid: 9744220].
206 Juan D, Zhou DHD, Li J, et al. A 2-year follow-up study of cigarette smoking and risk of dementia. Eur J Neurol. 2004;11(4):277-82. [pmid: 15061830].
207 Launer LJ, Andersen K, Dewey ME, et al. Rates and risk factors for dementia and Alzheimer's disease: results from EURODEM pooled analyses. EURODEM Incidence Research Group and Work Groups. European Studies of Dementia. Neurology. 1999;52(1):78-84. [pmid: 9921852].
208 Merchant C, Tang MX, Albert S, et al. The influence of smoking on the risk of Alzheimer's disease. Neurology. 1999;52(7):1408-12. [pmid: 10227626].
209 Moffat SD, Zonderman AB, Metter EJ, et al. Free testosterone and risk for Alzheimer disease in older men. Neurology. 2004;62(2):188-93. [pmid: 14745052].
210 Wang HX, Fratiglioni L, Frisoni GB, et al. Smoking and the occurrence of Alzheimer's disease: cross-sectional and longitudinal data in a population-based study. Am J Epidemiol. 1999;149(7):640-4. [pmid: 10192311].
211 Aggarwal NT, Bienias JL, Bennett DA, et al. The relation of cigarette smoking to incident Alzheimer's disease in a biracial urban community population. Neuroepidemiology. 2006;26(3):140-6. [pmid: 16493200].
212 Reitz C, den Heijer T, van Duijn C, et al. Relation between smoking and risk of dementia and Alzheimer disease: the Rotterdam Study. Neurology. 2007;69(10):998-1005. [pmid: 17785668].
213 Deng J, Zhou DH, Li J, et al. A 2-year follow-up study of alcohol consumption and risk of dementia. Clin Neurol Neurosurg. 2006;108(4):378-83. [pmid: 16084641].
214 Huang W, Qiu C, Winblad B, et al. Alcohol consumption and incidence of dementia in a community sample aged 75 years and older. J Clin Epidemiol. 2002;55(10):959-64. [pmid: 12464371].
215 Larrieu S, Letenneur L, Helmer C, et al. Nutritional factors and risk of incident dementia in the PAQUID longitudinal cohort. Journal of Nutrition, Health & Aging. 2004;8(3):150-4.
216 Luchsinger JA, Tang MX, Siddiqui M, et al. Alcohol intake and risk of dementia. J Am Geriatr Soc. 2004;52(4):540-6. [pmid: 15066068].
217 Mukamal KJ, Kuller LH, Fitzpatrick AL, et al. Prospective study of alcohol consumption and risk of dementia in older adults. JAMA. 2003;289(11):1405-13. [pmid: 12636463].
218 Ruitenberg A, van Swieten JC, Witteman JC, et al. Alcohol consumption and risk of dementia: the Rotterdam Study. Lancet. 2002;359(9303):281-6. [pmid: 11830193].
219 Shin IS, Stewart R, Kim JM, et al. Mitochondrial aldehyde dehydrogenase polymorphism is not associated with incidence of Alzheimer's disease. Int J Geriatr Psychiatry. 2005;20(11):1075-80. [pmid: 16250071].
220 Ganguli M, Vander Bilt J, Saxton JA, et al. Alcohol consumption and cognitive function in late life: a longitudinal community study. Neurology. 2005;65(8):1210-7. [pmid: 16247047].
221 Espeland MA, Gu L, Masaki KH, et al. Association between reported alcohol intake and cognition: results from the Women's Health Initiative Memory Study. Am J Epidemiol. 2005;161(3):228-38. [pmid: 15671255].
222 Tyas SL, Manfreda J, Strain LA, et al. Risk factors for Alzheimer's disease: a population-based, longitudinal study in Manitoba, Canada. Int J Epidemiol. 2001;30(3):590-7. [pmid: 11416089].
223 Baldi I, Lebailly P, Mohammed-Brahim B, et al. Neurodegenerative diseases and exposure to pesticides in the elderly. Am J Epidemiol. 2003;157(5):409-14. [pmid: 12615605].
224 Gauthier E, Fortier I, Courchesne F, et al. Environmental pesticide exposure as a risk factor for Alzheimer's disease: a case-control study. Environ Res. 2001;86(1):37-45. [pmid: 11386739].
225 Salib E, Hillier V. A case-control study of Alzheimer's disease and aluminium occupation. Br J Psychiatry. 1996;168(2):244-9. [pmid: 8837919].
226 Gun RT, Korten AE, Jorm AF, et al. Occupational risk factors for Alzheimer disease: a case-control study. Alzheimer Dis Assoc Disord. 1997;11(1):21-7. [pmid: 9071441].
227 Graves AB, Rosner D, Echeverria D, et al. Occupational exposures to solvents and aluminium and estimated risk of Alzheimer's disease. Occup Environ Med. 1998;55(9):627-33. [pmid: 9861186].
228 Rondeau V, Jacqmin-Gadda H, Commenges D, et al. Aluminum and silica in drinking water and the risk of Alzheimer's disease or cognitive decline: findings from 15-year follow-up of the PAQUID cohort. Am J Epidemiol. 2009;169(4):489-96. [pmid: 19064650].
229 Kennedy AM, Brown J, Rossor M. The genetics of Alzheimer's disease. Baillieres Clin Neurol. 1994;3(2):217-40. [pmid: 7952845].
230 Breitner JC, Welsh KA, Gau BA, et al. Alzheimer's disease in the National Academy of Sciences-National Research Council Registry of Aging Twin Veterans. III. Detection of cases, longitudinal results, and observations on twin concordance. Arch Neurol. 1995;52(8):763-71. [pmid: 7639628].
231 Pedersen NL, Gatz M, Berg S, et al. How heritable is Alzheimer's disease late in life? Findings from Swedish twins. Ann Neurol. 2004;55(2):180-5. [pmid: 14755721].
232 Gatz M, Pedersen NL, Berg S, et al. Heritability for Alzheimer's disease: the study of dementia in Swedish twins. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 1997;52(2):M117-25.
233 Farrer LA, Cupples LA, Haines JL, et al. Effects of age, sex, and ethnicity on the association between apolipoprotein E genotype and Alzheimer disease. A meta-analysis. APOE and Alzheimer Disease Meta Analysis Consortium. JAMA. 1997;278(16):1349-56. [pmid: 9343467].
234 Harold D, Abraham R, Hollingworth P, et al. Genome-wide association study identifies variants at CLU and PICALM associated with Alzheimer's disease.[Erratum appears in Nat Genet. 2009 Oct;41(10):1156]. Nat Genet. 2009;41(10):1088-93. [pmid: 19734902].
235 Lambert JC, Heath S, Even G, et al. Genome-wide association study identifies variants at CLU and CR1 associated with Alzheimer's disease. Nat Genet. 2009;41(10):1094-9. [pmid: 19734903].
236 Morris MC, Evans DA, Bienias JL, et al. Dietary folate and vitamin B12 intake and cognitive decline among community-dwelling older persons. Arch Neurol. 2005;62(4):641-5. [pmid: 15824266].
237 Clarke R, Birks J, Nexo E, et al. Low vitamin B-12 status and risk of cognitive decline in older adults. Am J Clin Nutr. 2007;86(5):1384-91. [pmid: 17991650].
238 Kado DM, Karlamangla AS, Huang MH, et al. Homocysteine versus the vitamins folate, B6, and B12 as predictors of cognitive function and decline in older high-functioning adults: MacArthur Studies of Successful Aging. Am J Med. 2005;118(2):161-7. [pmid: 15694902].
239 de Lau LM, Smith AD, Refsum H, et al. Plasma vitamin B12 status and cerebral white-matter lesions. J Neurol Neurosurg Psychiatry. 2009;80(2):149-57. [pmid: 18977824].
240 Fotuhi M, Zandi PP, Hayden KM, et al. Better cognitive performance in elderly taking antioxidant vitamins E and C supplements in combination with nonsteroidal anti-inflammatory drugs: the Cache County Study. Alzheimers Dement. 2008;4(3):223-7. [pmid: 18631971].
241 Morris MC, Evans DA, Bienias JL, et al. Vitamin E and cognitive decline in older persons. Arch Neurol. 2002;59(7):1125-32. [pmid: 12117360].
242 Wengreen HJ, Munger RG, Corcoran CD, et al. Antioxidant intake and cognitive function of elderly men and women: the Cache County Study. J Nutr Health Aging. 2007;11(3):230-7. [pmid: 17508099].
243 Kang JH, Grodstein F. Plasma carotenoids and tocopherols and cognitive function: a prospective study. Neurobiol Aging. 2008;29(9):1394-403. [pmid: 17433501].
244 Kalmijn S, Feskens EJ, Launer LJ, et al. Polyunsaturated fatty acids, antioxidants, and cognitive function in very old men. Am J Epidemiol. 1997;145(1):33-41. [pmid: 8982020].
245 Berr C, Balansard B, Arnaud J, et al. Cognitive decline is associated with systemic oxidative stress: the EVA study. Etude du Vieillissement Arteriel. J Am Geriatr Soc. 2000;48(10):1285-91. [pmid: 11037017].
246 Morris MC, Evans DA, Tangney CC, et al. Fish consumption and cognitive decline with age in a large community study. Arch Neurol. 2005;62(12):1849-53. [pmid: 16216930].
247 van Gelder BM, Tijhuis M, Kalmijn S, et al. Fish consumption, n-3 fatty acids, and subsequent 5-y cognitive decline in elderly men: the Zutphen Elderly Study. Am J Clin Nutr. 2007;85(4):1142-7. [pmid: 17413117].
248 Heude B, Ducimetiere P, Berr C. Cognitive decline and fatty acid composition of erythrocyte membranes--The EVA Study. Am J Clin Nutr. 2003;77(4):803-8. [pmid: 12663275].
249 Beydoun MA, Kaufman JS, Satia JA, et al. Plasma n-3 fatty acids and the risk of cognitive decline in older adults: the Atherosclerosis Risk in Communities Study. Am J Clin Nutr. 2007;85(4):1103-11. [pmid: 17413112].
250 Beydoun MA, Kaufman JS, Sloane PD, et al. n-3 Fatty acids, hypertension and risk of cognitive decline among older adults in the Atherosclerosis Risk in Communities (ARIC) study. Public Health Nutr. 2008;11(1):17-29. [pmid: 17625029].
251 Dullemeijer C, Durga J, Brouwer IA, et al. n 3 fatty acid proportions in plasma and cognitive performance in older adults. Am J Clin Nutr. 2007;86(5):1479-85. [pmid: 17991662].
252 Morris MC, Evans DA, Bienias JL, et al. Dietary fat intake and 6-year cognitive change in an older biracial community population. Neurology. 2004;62(9):1573-9. [pmid: 15136684].
253 Morris MC, Evans DA, Tangney CC, et al. Dietary copper and high saturated and trans fat intakes associated with cognitive decline. Arch Neurol. 2006;63(8):1085-8. [pmid: 16908733].
254 Akbaraly TN, Hininger-Favier I, Carriere I, et al. Plasma selenium over time and cognitive decline in the elderly. Epidemiology. 2007;18(1):52-8. [pmid: 17130689].
255 Kang JH, Ascherio A, Grodstein F. Fruit and vegetable consumption and cognitive decline in aging women. Ann Neurol. 2005;57(5):713-20. [pmid: 15852398].
256 Morris MC, Evans DA, Tangney CC, et al. Associations of vegetable and fruit consumption with age-related cognitive change. Neurology. 2006;67(8):1370-6. [pmid: 17060562].
257 Cherbuin N, Reglade-Meslin C, Kumar R, et al. Risk factors of transition from normal cognition to mild cognitive disorder: the PATH through Life Study. Dement Geriatr Cogn Disord. 2009;28(1):47-55. [pmid: 19628940].
258 Yaffe K, Fiocco AJ, Lindquist K, et al. Predictors of maintaining cognitive function in older adults: the Health ABC study. Neurology. 2009;72(23):2029-35. [pmid: 19506226].
259 Comijs HC, Kriegsman DM, Dik MG, et al. Somatic chronic diseases and 6-year change in cognitive functioning among older persons. Arch Gerontol Geriatr. 2009;48(2):191-6. [pmid: 18299158].
260 Knopman DS, Mosley TH, Catellier DJ, et al. Fourteen-year longitudinal study of vascular risk factors, APOE genotype, and cognition: the ARIC MRI Study. Alzheimers Dement. 2009;5(3):207-14. [pmid: 19362884].
261 Devore EE, Kang JH, Okereke O, et al. Physical activity levels and cognition in women with type 2 diabetes. Am J Epidemiol. 2009;170(8):1040-7. [pmid: 19729385].
262 Carmelli D, Swan GE, Reed T, et al. Midlife cardiovascular risk factors, ApoE, and cognitive decline in elderly male twins. Neurology. 1998;50(6):1580-5. [pmid: 9633697].
263 Yaffe K, Kanaya A, Lindquist K, et al. The metabolic syndrome, inflammation, and risk of cognitive decline. JAMA. 2004;292(18):2237-42. [pmid: 15536110].
264 van den Berg E, Biessels GJ, de Craen AJ, et al. The metabolic syndrome is associated with decelerated cognitive decline in the oldest old. Neurology. 2007;69(10):979-85. [pmid: 17785666].
265 Ho RC, Niti M, Yap KB, et al. Metabolic syndrome and cognitive decline in chinese older adults: results from the singapore longitudinal ageing studies. Am J Geriatr Psychiatry. 2008;16(6):519-22. [pmid: 18515697].
266 Solfrizzi V, Panza F, Colacicco AM, et al. Vascular risk factors, incidence of MCI, and rates of progression to dementia. Neurology. 2004;63(10):1882-91. [pmid: 15557506].
267 Tervo S, Kivipelto M, Hanninen T, et al. Incidence and risk factors for mild cognitive impairment: a population-based three-year follow-up study of cognitively healthy elderly subjects. Dement Geriatr Cogn Disord. 2004;17(3):196-203. [pmid: 14739544].
268 Reitz C, Tang MX, Manly J, et al. Hypertension and the risk of mild cognitive impairment. Arch Neurol. 2007;64(12):1734-40. [pmid: 18071036].
269 Alves de Moraes S, Szklo M, Knopman D, et al. The relationship between temporal changes in blood pressure and changes in cognitive function: atherosclerosis risk in communities (ARIC) study. Prev Med. 2002;35(3):258-63. [pmid: 12202068].
270 Knopman D, Boland LL, Mosley T, et al. Cardiovascular risk factors and cognitive decline in middle-aged adults. Neurology. 2001;56(1):42-8. [pmid: 11148234].
271 Barnes DE, Cauley JA, Lui LY, et al. Women who maintain optimal cognitive function into old age. J Am Geriatr Soc. 2007;55(2):259-64. [pmid: 17302664].
272 Swan GE, DeCarli C, Miller BL, et al. Association of midlife blood pressure to late-life cognitive decline and brain morphology. Neurology. 1998;51(4):986-93. [pmid: 9781518].
273 Gurland BJ, Teresi J, Smith WM, et al. Effects of treatment for isolated systolic hypertension on cognitive status and depression in the elderly. J Am Geriatr Soc. 1988;36(11):1015-22. [pmid: 3171039].
274 Haan MN, Shemanski L, Jagust WJ, et al. The role of APOE epsilon4 in modulating effects of other risk factors for cognitive decline in elderly persons. JAMA. 1999;282(1):40-6. [pmid: 10404910].
275 Hebert LE, Scherr PA, Bennett DA, et al. Blood pressure and late-life cognitive function change: a biracial longitudinal population study. Neurology. 2004;62(11):2021-4. [pmid: 15184608].
276 Insel KC, Palmer RF, Stroup-Benham CA, et al. Association between change in systolic blood pressure and cognitive decline among elderly Mexican Americans: data from the Hispanic established population for epidemiology study of the elderly. Exp Aging Res. 2005;31(1):35-54. [pmid: 15842072].
277 Kuo HK, Jones RN, Milberg WP, et al. Effect of blood pressure and diabetes mellitus on cognitive and physical functions in older adults: a longitudinal analysis of the advanced cognitive training for independent and vital elderly cohort. J Am Geriatr Soc. 2005;53(7):1154-61. [pmid: 16108933].
278 Tzourio C, Dufouil C, Ducimetiere P, et al. Cognitive decline in individuals with high blood pressure: a longitudinal study in the elderly. EVA Study Group. Epidemiology of Vascular Aging. Neurology. 1999;53(9):1948-52. [pmid: 10599763].
279 Waldstein SR, Giggey PP, Thayer JF, et al. Nonlinear relations of blood pressure to cognitive function: the Baltimore Longitudinal Study of Aging. Hypertension. 2005;45(3):374-9. [pmid: 15699446].
280 Glynn RJ, Beckett LA, Hebert LE, et al. Current and remote blood pressure and cognitive decline. JAMA. 1999;281(5):438-45. [pmid: 9952204].
281 Kivipelto M, Helkala EL, Hanninen T, et al. Midlife vascular risk factors and late-life mild cognitive impairment: A population-based study. Neurology. 2001;56(12):1683-9. [pmid: 11425934].
282 Kalmijn S, Feskens EJ, Launer LJ, et al. Cerebrovascular disease, the apolipoprotein e4 allele, and cognitive decline in a community-based study of elderly men. Stroke. 1996;27(12):2230-5. [pmid: 8969786].
283 Reitz C, Luchsinger J, Tang MX, et al. Impact of plasma lipids and time on memory performance in healthy elderly without dementia. Neurology. 2005;64(8):1378-83. [pmid: 15851727].
284 Packard C, Westendorp R, Stott D, et al. Association between apolipoprotein E4 and cognitive decline in elderly adults. J Am Geriatr Soc. 2007;55(11):1777-85. [pmid: 17979899].
285 Dufouil C, Alperovitch A, Ducros V, et al. Homocysteine, white matter hyperintensities, and cognition in healthy elderly people. Ann Neurol. 2003;53(2):214-21. [pmid: 12557288].
286 Kalmijn S, Launer LJ, Lindemans J, et al. Total homocysteine and cognitive decline in a community-based sample of elderly subjects: the Rotterdam Study. Am J Epidemiol. 1999;150(3):283-9. [pmid: 10430233].
287 Sturman MT, de Leon CF, Bienias JL, et al. Body mass index and cognitive decline in a biracial community population. Neurology. 2008;70(5):360-7. [pmid: 17881716].
288 Barnes DE, Alexopoulos GS, Lopez OL, et al. Depressive symptoms, vascular disease, and mild cognitive impairment: findings from the Cardiovascular Health Study. Arch Gen Psychiatry. 2006;63(3):273-9. [pmid: 16520432].
289 Christensen H, Henderson AS, Korten AE, et al. ICD-10 mild cognitive disorder: its outcome three years later. Int J Geriatr Psychiatry. 1997;12(5):581-6. [pmid: 9193969].
290 Dufouil C, Fuhrer R, Dartigues JF, et al. Longitudinal analysis of the association between depressive symptomatology and cognitive deterioration. Am J Epidemiol. 1996;144(7):634-41. [pmid: 8823058].
291 Geda YE, Knopman DS, Mrazek DA, et al. Depression, apolipoprotein E genotype, and the incidence of mild cognitive impairment: a prospective cohort study. Arch Neurol. 2006;63(3):435-40. [pmid: 16533972].
292 Geerlings MI, Schoevers RA, Beekman AT, et al. Depression and risk of cognitive decline and Alzheimer's disease. Results of two prospective community-based studies in The Netherlands. Br J Psychiatry. 2000;176:568-75. [pmid: 10974964].
293 Ng TP, Niti M, Zaw MH, et al. Depressive symptoms and incident cognitive impairment in cognitively well-functioning older men and women. J Am Geriatr Soc. 2009;57(6):1058-63. [pmid: 19467145].
294 Panza F, D'Introno A, Colacicco AM, et al. Depressive symptoms, vascular risk factors and mild cognitive impairment. The Italian longitudinal study on aging. Dement Geriatr Cogn Disord. 2008;25(4):336-46. [pmid: 18319599].
295 Paterniti S, Verdier-Taillefer MH, Dufouil C, et al. Depressive symptoms and cognitive decline in elderly people. Longitudinal study. Br J Psychiatry. 2002;181:406-10. [pmid: 12411266].
296 Ravaglia G, Forti P, Lucicesare A, et al. Prevalent depressive symptoms as a risk factor for conversion to mild cognitive impairment in an elderly Italian cohort. Am J Geriatr Psychiatry. 2008;16(10):834-43. [pmid: 18827230].
297 Wilson RS, Schneider JA, Boyle PA, et al. Chronic distress and incidence of mild cognitive impairment. Neurology. 2007;68(24):2085-92. [pmid: 17562829].
298 Yaffe K, Blackwell T, Gore R, et al. Depressive symptoms and cognitive decline in nondemented elderly women: a prospective study. Arch Gen Psychiatry. 1999;56(5):425-30. [pmid: 10232297].
299 Chodosh J, Kado DM, Seeman TE, et al. Depressive symptoms as a predictor of cognitive decline: MacArthur Studies of Successful Aging. Am J Geriatr Psychiatry. 2007;15(5):406-15. [pmid: 17353297].
300 Comijs HC, Jonker C, Beekman AT, et al. The association between depressive symptoms and cognitive decline in community-dwelling elderly persons. Int J Geriatr Psychiatry. 2001;16(4):361-7. [pmid: 11333422].
301 Dotson VM, Resnick SM, Zonderman AB. Differential association of concurrent, baseline, and average depressive symptoms with cognitive decline in older adults. Am J Geriatr Psychiatry. 2008;16(4):318-30. [pmid: 18378557].
302 Ganguli M, Du Y, Dodge HH, et al. Depressive symptoms and cognitive decline in late life: a prospective epidemiological study. Arch Gen Psychiatry. 2006;63(2):153-60. [pmid: 16461857].
303 Gonzalez HM, Bowen ME, Fisher GG. Memory decline and depressive symptoms in a nationally representative sample of older adults: the Health and Retirement Study (1998–2004). Dement Geriatr Cogn Disord. 2008;25(3):266-71. [pmid: 18270489].
304 Prince M, Lewis G, Bird A, et al. A longitudinal study of factors predicting change in cognitive test scores over time, in an older hypertensive population. Psychol Med. 1996;26(3):555-68. [pmid: 8733214].
305 Rabbitt P, Lunn M, Ibrahim S, et al. Unhappiness, health and cognitive ability in old age. Psychol Med. 2008;38(2):229-36. [pmid: 17988418].
306 Raji MA, Reyes-Ortiz CA, Kuo YF, et al. Depressive symptoms and cognitive change in older Mexican Americans. J Geriatr Psychiatry Neurol. 2007;20(3):145-52. [pmid: 17712097].
307 Wilson RS, Mendes De Leon CF, Bennett DA, et al. Depressive symptoms and cognitive decline in a community population of older persons. J Neurol Neurosurg Psychiatry. 2004;75(1):126-9. [pmid: 14707321].
308 Niti M, Yap KB, Kua EH, et al. APOE-epsilon4, depressive symptoms, and cognitive decline in Chinese older adults: Singapore Longitudinal Aging Studies. J Gerontol A Biol Sci Med Sci. 2009;64(2):306-11. [pmid: 19181718].
309 Bierman EJ, Comijs HC, Rijmen F, et al. Anxiety symptoms and cognitive performance in later life: results from the longitudinal aging study Amsterdam. Aging Ment Health. 2008;12(4):517-23. [pmid: 18791901].
310 Gallacher J, Bayer A, Fish M, et al. Does anxiety affect risk of dementia? Findings from the Caerphilly Prospective Study. Psychosom Med. 2009;71(6):659-66. [pmid: 19553290].
311 Wetherell JL, Reynolds CA, Gatz M, et al. Anxiety, cognitive performance, and cognitive decline in normal aging. J Gerontol B Psychol Sci Soc Sci. 2002;57(3):P246-55. [pmid: 11983736].
312 Agostini JV, Tinetti ME, Han L, et al. Effects of statin use on muscle strength, cognition, and depressive symptoms in older adults. J Am Geriatr Soc. 2007;55(3):420-5. [pmid: 17341246].
313 Bernick C, Katz R, Smith N, et al. Statins and cognitive function in the elderly: the Cardiovascular Health Study. Neurology. 2005;65(9):1388-94. [pmid: 16275825].
314 Szwast SJ, Hendrie H, Lane K, et al. Association of statin use with cognitive decline in elderly African Americans. Neurology. 2007;69(19):1873-80. [pmid: 17984456].
315 Hayden KM, Zandi PP, Khachaturian AS, et al. Does NSAID use modify cognitive trajectories in the elderly? The Cache County study. Neurology. 2007;69(3):275-82. [pmid: 17636065].
316 Jonker C, Comijs HC, Smit JH. Does aspirin or other NSAIDs reduce the risk of cognitive decline in elderly persons? Results from a population-based study. Neurobiol Aging. 2003;24(4):583-8. [pmid: 12714115].
317 Grodstein F, Skarupski KA, Bienias JL, et al. Anti-inflammatory agents and cognitive decline in a biracial population. Neuroepidemiology. 2008;30(1):45-50. [pmid: 18259082].
318 Hee Kang J, Grodstein F. Regular use of nonsteroidal anti-inflammatory drugs and cognitive function in aging women. Neurology. 2003;60(10):1591-7. [pmid: 12771247].
319 Ryan J, Carriere I, Scali J, et al. Life-time estrogen exposure and cognitive functioning in later life. Psychoneuroendocrinology. 2009;34(2):287-98. [pmid: 18947934].
320 Everson-Rose SA, Mendes de Leon CF, Bienias JL, et al. Early life conditions and cognitive functioning in later life. Am J Epidemiol. 2003;158(11):1083-9. [pmid: 14630604].
321 Graves AB, Rajaram L, Bowen JD, et al. Cognitive decline and Japanese culture in a cohort of older Japanese Americans in King County, WA: the Kame Project. J Gerontol B Psychol Sci Soc Sci. 1999;54(3):S154-61. [pmid: 10363046].
322 Alvarado BE, Zunzunegui MV, Del Ser T, et al. Cognitive decline is related to education and occupation in a Spanish elderly cohort. Aging Clin Exp Res. 2002;14(2):132-42. [pmid: 12092786].
323 Koster A, Penninx BW, Bosma H, et al. Socioeconomic differences in cognitive decline and the role of biomedical factors. Ann Epidemiol. 2005;15(8):564-71. [pmid: 15922627].
324 Lee S, Buring JE, Cook NR, et al. The relation of education and income to cognitive function among professional women. Neuroepidemiology. 2006;26(2):93-101. [pmid: 16352912].
325 Lee S, Kawachi I, Berkman LF, et al. Education, other socioeconomic indicators, and cognitive function. Am J Epidemiol. 2003;157(8):712-20. [pmid: 12697575].
326 Kalmijn S, Feskens EJ, Launer LJ, et al. Longitudinal study of the effect of apolipoprotein e4 allele on the association between education and cognitive decline in elderly men. BMJ. 1997;314(7073):34-5. [pmid: 9001477].
327 Manly JJ, Schupf N, Tang MX, et al. Cognitive decline and literacy among ethnically diverse elders. J Geriatr Psychiatry Neurol. 2005;18(4):213-7. [pmid: 16306242].
328 Wilson RS, Hebert LE, Scherr PA, et al. Educational attainment and cognitive decline in old age. Neurology. 2009;72(5):460-5. [pmid: 19188578].
329 Karlamangla AS, Miller-Martinez D, Aneshensel CS, et al. Trajectories of cognitive function in late life in the United States: demographic and socioeconomic predictors. Am J Epidemiol. 2009;170(3):331-42. [pmid: 19605514].
330 Shadlen MF, Larson EB, Wang L, et al. Education modifies the effect of apolipoprotein epsilon 4 on cognitive decline. Neurobiol Aging. 2005;26(1):17-24. [pmid: 15585342].
331 Christensen H, Batterham PJ, Mackinnon AJ, et al. The association of APOE genotype and cognitive decline in interaction with risk factors in a 65–69 year old community sample. BMC Geriatr. 2008;8:14. [pmid: 18620605].
332 Winnock M, Letenneur L, Jacqmin-Gadda H, et al. Longitudinal analysis of the effect of apolipoprotein E epsilon4 and education on cognitive performance in elderly subjects: the PAQUID study. J Neurol Neurosurg Psychiatry. 2002;72(6):794-7. [pmid: 12023428].
333 Potter GG, Plassman BL, Helms MJ, et al. Occupational characteristics and cognitive performance among elderly male twins. Neurology. 2006;67(8):1377-82. [pmid: 17060563].
334 Virtanen M, Singh-Manoux A, Ferrie JE, et al. Long working hours and cognitive function: the Whitehall II Study. Am J Epidemiol. 2009;169(5):596-605. [pmid: 19126590].
335 Yu F, Ryan LH, Schaie KW, et al. Factors associated with cognition in adults: the Seattle Longitudinal Study. Res Nurs Health. 2009;32(5):540-50. [pmid: 19606423].
336 Barnes LL, Mendes de Leon CF, Wilson RS, et al. Social resources and cognitive decline in a population of older African Americans and whites. Neurology. 2004;63(12):2322-6. [pmid: 15623694].
337 Holtzman RE, Rebok GW, Saczynski JS, et al. Social network characteristics and cognition in middle-aged and older adults. J Gerontol B Psychol Sci Soc Sci. 2004;59(6):P278-84. [pmid: 15576855].
338 Green AF, Rebok G, Lyketsos CG. Influence of social network characteristics on cognition and functional status with aging. Int J Geriatr Psychiatry. 2008;23(9):972-8. [pmid: 18449952].
339 Seeman TE, Lusignolo TM, Albert M, et al. Social relationships, social support, and patterns of cognitive aging in healthy, high-functioning older adults: MacArthur studies of successful aging. Health Psychol. 2001;20(4):243-55. [pmid: 11515736].
340 Aartsen MJ, Van Tilburg T, Smits CH, et al. Does widowhood affect memory performance of older persons?. Psychol Med. 2005;35(2):217-26. [pmid: 15841679].
341 van Gelder BM, Tijhuis M, Kalmijn S, et al. Marital status and living situation during a 5-year period are associated with a subsequent 10-year cognitive decline in older men: the FINE Study. J Gerontol B Psychol Sci Soc Sci. 2006;61(4):P213-9. [pmid: 16855033].
342 Ho SC, Woo J, Sham A, et al. A 3-year follow-up study of social, lifestyle and health predictors of cognitive impairment in a Chinese older cohort. Int J Epidemiol. 2001;30(6):1389-96. [pmid: 11821352].
343 Zunzunegui MV, Alvarado BE, Del Ser T, et al. Social networks, social integration, and social engagement determine cognitive decline in community-dwelling Spanish older adults. J Gerontol B Psychol Sci Soc Sci. 2003;58(2):S93-S100. [pmid: 12646598].
344 Muniz-Terrera G, Matthews F, Dening T, et al. Education and trajectories of cognitive decline over 9 years in very old people: methods and risk analysis. Age Ageing. 2009;38(3):277-82. [pmid: 19252209].
345 Verghese J, LeValley A, Derby C, et al. Leisure activities and the risk of amnestic mild cognitive impairment in the elderly. Neurology. 2006;66(6):821-7. [pmid: 16467493].
346 Wilson RS, Bennett DA, Bienias JL, et al. Cognitive activity and cognitive decline in a biracial community population. Neurology. 2003;61(6):812-6. [pmid: 14504326].
347 Bosma H, van Boxtel MP, Ponds RW, et al. Engaged lifestyle and cognitive function in middle and old-aged, non-demented persons: a reciprocal association?. Z Gerontol Geriatr. 2002;35(6):575-81. [pmid: 12491004].
348 Lytle ME, Vander Bilt J, Pandav RS, et al. Exercise level and cognitive decline: the MoVIES project. Alzheimer Dis Assoc Disord. 2004;18(2):57-64. [pmid: 15249848].
349 Schuit AJ, Feskens EJ, Launer LJ, et al. Physical activity and cognitive decline, the role of the apolipoprotein e4 allele. Med Sci Sports Exerc. 2001;33(5):772-7. [pmid: 11323547].
350 Yaffe K, Barnes D, Nevitt M, et al. A prospective study of physical activity and cognitive decline in elderly women: women who walk. Arch Intern Med. 2001;161(14):1703-8. [pmid: 11485502].
351 Weuve J, Kang JH, Manson JE, et al. Physical activity, including walking, and cognitive function in older women. JAMA. 2004;292(12):1454-61. [pmid: 15383516].
352 Niti M, Yap KB, Kua EH, et al. Physical, social and productive leisure activities, cognitive decline and interaction with APOE-epsilon 4 genotype in Chinese older adults. Int Psychogeriatr. 2008;20(2):237-51. [pmid: 18190728].
353 Weisskopf MG, Wright RO, Schwartz J, et al. Cumulative lead exposure and prospective change in cognition among elderly men: the VA Normative Aging Study. Am J Epidemiol. 2004;160(12):1184-93. [pmid: 15583371].
354 Launer LJ, Feskens EJ, Kalmijn S, et al. Smoking, drinking, and thinking. The Zutphen Elderly Study. Am J Epidemiol. 1996;143(3):219-27. [pmid: 8561155].
355 Ott A, Andersen K, Dewey ME, et al. Effect of smoking on global cognitive function in nondemented elderly. Neurology. 2004;62(6):920-4. [pmid: 15037693].
356 Whittington J, FAH. Smoking and cognitive decline. Human Psychopharmacology. 1997;12:467-80.
357 Graves AB, Bowen JD, Rajaram L, et al. Impaired olfaction as a marker for cognitive decline: interaction with apolipoprotein E epsilon4 status. Neurology. 1999;53(7):1480-7. [pmid: 10534255].
358 Lui L-Y, Stone K, Cauley JA, et al. Bone loss predicts subsequent cognitive decline in older women: the study of osteoporotic fractures. J Am Geriatr Soc. 2003;51(1):38-43. [pmid: 12534843].
359 Paleologos M, Cumming RG, Lazarus R. Cohort study of vitamin C intake and cognitive impairment. Am J Epidemiol. 1998;148(1):45-50. [pmid: 9663403].
360 Ford AB, Mefrouche Z, Friedland RP, et al. Smoking and cognitive impairment: a population-based study. J Am Geriatr Soc. 1996;44(8):905-9. [pmid: 8708298].
361 Reitz C, Luchsinger J, Tang MX, et al. Effect of smoking and time on cognitive function in the elderly without dementia. Neurology. 2005;65(6):870-5. [pmid: 16186526].
362 Dufouil C, Tzourio C, Brayne C, et al. Influence of apolipoprotein E genotype on the risk of cognitive deterioration in moderate drinkers and smokers. Epidemiology. 2000;11(3):280-4. [pmid: 10784244].
363 Wright CB, Elkind MS, Luo X, et al. Reported alcohol consumption and cognitive decline: The northern Manhattan study. Neuroepidemiology. 2006;27(4):201-7. [pmid: 17047373].
364 Stott DJ, Falconer A, Kerr GD, et al. Does low to moderate alcohol intake protect against cognitive decline in older people?. J Am Geriatr Soc. 2008;56(12):2217-24. [pmid: 19093921].
365 Solfrizzi V, D'Introno A, Colacicco AM, et al. Alcohol consumption, mild cognitive impairment, and progression to dementia. Neurology. 2007;68(21):1790-9. [pmid: 17515541].
366 Wilson RS, Bienias JL, Berry-Kravis E, et al. The apolipoprotein E epsilon 2 allele and decline in episodic memory. J Neurol Neurosurg Psychiatry. 2002;73(6):672-7. [pmid: 12438469].
367 Bretsky P, Guralnik JM, Launer L, et al. The role of APOE-epsilon4 in longitudinal cognitive decline: MacArthur Studies of Successful Aging. Neurology. 2003;60(7):1077-81. [pmid: 12682309].
368 Blair CK, Folsom AR, Knopman DS, et al. APOE genotype and cognitive decline in a middle-aged cohort. Neurology. 2005;64(2):268-76. [pmid: 15668424].
369 Staehelin HB, Perrig-Chiello P, Mitrache C, et al. Apolipoprotein E genotypes and cognitive functions in healthy elderly persons. Acta Neurol Scand. 1999;100(1):53-60. [pmid: 10416512].
370 Yaffe K, Cauley J, Sands L, et al. Apolipoprotein E phenotype and cognitive decline in a prospective study of elderly community women. Arch Neurol. 1997;54(9):1110-4. [pmid: 9311354].
371 Dik MG, Jonker C, Bouter LM, et al. APOE-epsilon4 is associated with memory decline in cognitively impaired elderly. Neurology. 2000;54(7):1492-7. [pmid: 10751265].
372 Petersen RC, Thomas RG, Grundman M, et al. Vitamin E and donepezil for the treatment of mild cognitive impairment. N Engl J Med. 2005;352(23):2379-88. [pmid: 15829527].
373 DeKosky ST, Williamson JD, Fitzpatrick AL, et al. Ginkgo biloba for prevention of dementia: a randomized controlled trial. JAMA. 2008;300(19):2253-62. [pmid: 19017911].
374 Lithell H, Hansson L, Skoog I, et al. The Study on Cognition and Prognosis in the Elderly (SCOPE): principal results of a randomized double-blind intervention trial. J Hypertens. 2003;21(5):875-86. [pmid: 12714861].
375 Applegate WB, Pressel S, Wittes J, et al. Impact of the treatment of isolated systolic hypertension on behavioral variables. Results from the systolic hypertension in the elderly program. Arch Intern Med. 1994;154(19):2154-60. [pmid: 7944835].
376 Forette F, Seux ML, Staessen JA, et al. Prevention of dementia in randomised double-blind placebo-controlled Systolic Hypertension in Europe (Syst-Eur) trial. Lancet. 1998;352(9137):1347-51. [pmid: 9802273].
377 Forette F, Seux ML, Staessen JA, et al. The prevention of dementia with antihypertensive treatment: new evidence from the Systolic Hypertension in Europe (Syst-Eur) study. Arch Intern Med. 2002;162(18):2046-52. [pmid: 12374512].
378 Thal LJ, Ferris SH, Kirby L, et al. A randomized, double-blind, study of rofecoxib in patients with mild cognitive impairment. Neuropsychopharmacology. 2005;30(6):1204-15. [pmid: 15742005].
379 Adapt Research Group. Lyketsos CG, Breitner JC, et al. Naproxen and celecoxib do not prevent AD in early results from a randomized controlled trial. Neurology. 2007;68(21):1800-8. [pmid: 17460158].
380 Shumaker SA, Legault C, Rapp SR, et al. Estrogen plus progestin and the incidence of dementia and mild cognitive impairment in postmenopausal women: the Women's Health Initiative Memory Study: a randomized controlled trial. JAMA. 2003;289(20):2651-62. [pmid: 12771112].
381 Shumaker SA, Legault C, Kuller L, et al. Conjugated equine estrogens and incidence of probable dementia and mild cognitive impairment in postmenopausal women: Women's Health Initiative Memory Study. JAMA. 2004;291(24):2947-58. [pmid: 15213206].
382 Murthy A. A One-Year Multi-center, Randomized, Double-blind, Placebo-controlled Evaluation of the Efficacy and Safety of Donepezil Hydrochloride in Subjects with Mild Cognitive Impairment (MCI). Available at: http://www.clinicaltrials.gov/ct2/show/NCT00293176. Accessed on: September 24, 2009.
383 National Institute of Mental Health. University of Iowa. Cognitive Enhancers Explored with PET Imaging. ClinicalTrials.gov [Internet]. Bethesda (MD). National Library of Medicine (US). 2000. [cited 2009 Jul 09]. Available from: http://clinicaltrials.gov/ct/show/nct00042172.2002.
384 Novartis Efficacy and safety of Rivastigmine in patients with mild cognitive impairment. ClinicalTrialsgov [Internet]. Bethesda (MD). National Library of Medicine (US). 2000. [cited 2009 Jul 09]. Available from: http://clinicaltrials.gov/ct/show/nct00134953.2005.
385 Feldman HH, Ferris S, Winblad B, et al. Effect of rivastigmine on delay to diagnosis of Alzheimer's disease from mild cognitive impairment: the InDDEx study. Lancet Neurol. 2007;6(6):501-12. [pmid: 17509485].
386 Winblad B, Gauthier S, Scinto L, et al. Safety and efficacy of galantamine in subjects with mild cognitive impairment. Neurology. 2008;70(22):2024-35. [pmid: 18322263].
387 Petersen RC, Thomas RG, Grundman M, et al. Vitamin E and donepezil for the treatment of mild cognitive impairment. N Engl J Med. 2005;352(23):2379-88. [pmid: 15829527].
388 Diniz BS, Pinto JA Jr, Gonzaga ML, et al. To treat or not to treat? A meta-analysis of the use of cholinesterase inhibitors in mild cognitive impairment for delaying progression to Alzheimer's disease. Eur Arch Psychiatry Clin Neurosci. 2009;259(4):248-56. [pmid: 19224111].
389 Kang JH, Cook N, Manson J, et al. A trial of B vitamins and cognitive function among women at high risk of cardiovascular disease. Am J Clin Nutr. 2008;88(6):1602-10. [pmid: 19064521].
390 McMahon JA, Green TJ, Skeaff CM, et al. A controlled trial of homocysteine lowering and cognitive performance. N Engl J Med. 2006;354(26):2764-72. [pmid: 16807413].
391 McNeill G, Avenell A, Campbell MK, et al. Effect of multivitamin and multimineral supplementation on cognitive function in men and women aged 65 years and over: a randomised controlled trial. Nutr J. 2007;6:10. [pmid: 17474991].
392 Kang JH, Cook N, Manson J, et al. A randomized trial of vitamin E supplementation and cognitive function in women. Arch Intern Med. 2006;166(22):2462-8. [pmid: 17159011].
393 Smith A, Clark R, Nutt D, et al. Anti-Oxidant Vitamins and Mental Performance of the Elderly. Human Psychopharmacology Clinical and Experimental. 1999;14:459-471.
394 Kang JH, Cook NR, Manson JE, et al. Vitamin E, vitamin C, beta carotene, and cognitive function among women with or at risk of cardiovascular disease: The Women's Antioxidant and Cardiovascular Study. Circulation. 2009;119(21):2772-80. [pmid: 19451353].
395 Dodge HH, Zitzelberger T, Oken BS, et al. A randomized placebo-controlled trial of Ginkgo biloba for the prevention of cognitive decline. Neurology. 2008;70(19 Pt 2):1809-17. [pmid: 18305231].
396 van de Rest O, Geleijnse JM, Kok FJ, et al. Effect of fish oil on cognitive performance in older subjects: a randomized, controlled trial. Neurology. 2008;71(6):430-8. [pmid: 18678826].
397 Dangour AD, Clemens F, Elbourne D, et al. A randomised controlled trial investigating the effect of n-3 long-chain polyunsaturated fatty acid supplementation on cognitive and retinal function in cognitively healthy older people: the Older People And n-3 Long-chain polyunsaturated fatty acids (OPAL) study protocol [ISRCTN72331636]. Nutrition Journal. 2006;5:20. [pmid: 16945130].
398 Quinn J. A randomized double-blind placebo-controlled trial of the effects of docosahexaenoic acid (DHA) in slowing the progression of Alzheimer's disease. Available at: http://clinicaltrials.gov/ct2/show/NCT00440050. Accessed September 9, 2009.
399 Yurko-Mauro K. A randomized double-blind placebo-controlled study to evaluate the effects of DHA on cognitive function in the elderly. Available at: http://clinicaltrials.gov/ct2/show/NCT00278135. Accessed September 9, 2009.
400 Vakhapova V. A single-center, open-label study to assess the efficacy of SharpPS(TM)-Gold in elderly subjects with memory impairment. Available at: http://clincaltrials.gov/ct2/show/NCT00736034. Accessed September 9, 2009.
401 MRC/BHF Heart Protection Study of cholesterol lowering with simvastatin in 20,536 high-risk individuals: a randomised placebo-controlled trial.[summary for patients in Curr Cardiol Rep. 2002 Nov;4(6):486–7; PMID: 12379169]. Lancet. 2002;360(9326):7-22. [pmid: 12114036].
402 Shepherd J, Blauw GJ, Murphy MB, et al. Pravastatin in elderly individuals at risk of vascular disease (PROSPER): a randomised controlled trial. Lancet. 2002;360(9346):1623-30. [pmid: 12457784].
403 Saxby BK, Harrington F, Wesnes KA, et al. Candesartan and cognitive decline in older patients with hypertension: a substudy of the SCOPE trial. Neurology. 2008;70(19 Pt 2):1858-66. [pmid: 18458219].
404 Skoog I, Lithell H, Hansson L, et al. Effect of baseline cognitive function and antihypertensive treatment on cognitive and cardiovascular outcomes: Study on COgnition and Prognosis in the Elderly (SCOPE). Am J Hypertens. 2005;18(8):1052-9. [pmid: 16109319].
405 Prince MJ, Bird AS, Blizard RA, et al. Is the cognitive function of older patients affected by antihypertensive treatment? Results from 54 months of the Medical Research Council's trial of hypertension in older adults. BMJ. 1996;312(7034):801-5. [pmid: 8608285].
406 Tzourio C, Anderson C, Chapman N, et al. Effects of blood pressure lowering with perindopril and indapamide therapy on dementia and cognitive decline in patients with cerebrovascular disease. Arch Intern Med. 2003;163(9):1069-75. [pmid: 12742805].
407 Lithell H, Hansson L, Skoog I, et al. The Study on COgnition and Prognosis in the Elderly (SCOPE); outcomes in patients not receiving add-on therapy after randomization. J Hypertens. 2004;22(8):1605-12. [pmid: 15257185].
408 Di Bari M, Pahor M, Franse LV, et al. Dementia and disability outcomes in large hypertension trials: lessons learned from the systolic hypertension in the elderly program (SHEP) trial. Am J Epidemiol. 2001;153(1):72-8. [pmid: 11159149].
409 Price JF, Stewart MC, Deary IJ, et al. Low dose aspirin and cognitive function in middle aged to elderly adults: randomised controlled trial. BMJ. 2008;337:a1198. [pmid: 18762476].
410 Hee Kang J, Cook N, Manson J, et al. Low dose aspirin and cognitive function in the women's health study cognitive cohort. BMJ. 2007;334(7601):987. [pmid: 17468120].
411 Martin BK, Szekely C, Brandt J, et al. Cognitive function over time in the Alzheimer's Disease Anti-inflammatory Prevention Trial (ADAPT): results of a randomized, controlled trial of naproxen and celecoxib. Arch Neurol. 2008;65(7):896-905. [pmid: 18474729].
412 Tierney MC, Oh P, Moineddin R, et al. A randomized double-blind trial of the effects of hormone therapy on delayed verbal recall in older women. Psychoneuroendocrinology. 2009;34(7):1065-74. [pmid: 19297102].
413 Kritz-Silverstein D, von Muhlen D, Laughlin GA, et al. Effects of dehydroepiandrosterone supplementation on cognitive function and quality of life: the DHEA and Well-Ness (DAWN) Trial. J Am Geriatr Soc. 2008;56(7):1292-8. [pmid: 18482290].
414 Koontz J, Baskys A. Effects of galantamine on working memory and global functioning in patients with mild cognitive impairment: a double-blind placebo-controlled study. Am J Alzheimers Dis Other Demen. 2005;20(5):295-302. [pmid: 16273995].
415 Salloway S, Ferris S, Kluger A, et al. Efficacy of donepezil in mild cognitive impairment: a randomized placebo-controlled trial. Neurology. 2004;63(4):651-7. [pmid: 15326237].
416 Doody RS, Ferris SH, Salloway S, et al. Donepezil treatment of patients with MCI: a 48-week randomized, placebo-controlled trial. Neurology. 2009;72(18):1555-61. [pmid: 19176895].
417 Yesavage JA, Friedman L, Ashford JW, et al. Acetylcholinesterase inhibitor in combination with cognitive training in older adults. J Gerontol B Psychol Sci Soc Sci. 2008;63(5):P288-94. [pmid: 18818443].
418 Willis SL, Tennstedt SL, Marsiske M, et al. Long-term effects of cognitive training on everyday functional outcomes in older adults. JAMA. 2006;296(23):2805-14. [pmid: 17179457].
419 Unverzagt FW, Kasten L, Johnson KE, et al. Effect of memory impairment on training outcomes in ACTIVE. J Int Neuropsychol Soc. 2007;13(6):953-60. [pmid: 17942013].
420 Ball K, Berch DB, Helmers KF, et al. Effects of cognitive training interventions with older adults: a randomized controlled trial. JAMA. 2002;288(18):2271-81. [pmid: 12425704].
421 Lautenschlager NT, Cox KL, Flicker L, et al. Effect of physical activity on cognitive function in older adults at risk for Alzheimer disease: a randomized trial. JAMA. 2008;300(9):1027-37. [pmid: 18768414].
422 Caselli RJ, Dueck AC, Osborne D, et al. Longitudinal modeling of age-related memory decline and the APOE epsilon4 effect. N Engl J Med. 2009;361(3):255-63. [pmid: 19605830].
423 Ambrosius W, Chew E. Action to Control Cardiovascular Risk in Diabetes (ACCORD) Eye Study. Available at: http://clinicaltrials.gov/ct2/show/NCT00542178. Accessed October 1, 2009.
424 Launer L. Action to Control Cardiovascular Risk in Diabetes -- Memory in Diabetes. Available at: http://clinicaltrials.gov/ct2/show/NCT00182910. Accessed October 1, 2009.
425 Ben-Shlomo Y, Kuh D, Ben-Shlomo Y, et al. A life course approach to chronic disease epidemiology: conceptual models, empirical challenges and interdisciplinary perspectives. Int J Epidemiol. 2002;31(2):285-93. [pmid: 11980781].
426 West SG, Duan N, Pequegnat W, et al. Alternatives to the randomized controlled trial. Am J Public Health. 2008;98(8):1359-66. [pmid: 18556609].
427 Chatfield MD, Brayne CE, Matthews FE, et al. A systematic literature review of attrition between waves in longitudinal studies in the elderly shows a consistent pattern of dropout between differing studies. J Clin Epidemiol. 2005;58(1):13-9. [pmid: 15649666].
428 Robinson KA, Dennison CR, Wayman DM, et al. Systematic review identifies number of strategies important for retaining study participants. J Clin Epidemiol. 2007;60(8):757-65. [pmid: 17606170].
429 von Elm E, Altman DG, Egger M, et al. The Strengthening the Reporting of Observational Studies in Epidemiology (STROBE) statement: guidelines for reporting observational studies. Epidemiology. 2007;18(6):800-4. [pmid: 18049194].
430 Gershon R. NIH. Toolboox: Assessment of Neurological and Behavioral Function. Available at: http://www.nihtoolbox.org/default.aspx. Accessed October 1, 2009.
431 Wimo A, Winblad B, Stoffler A, et al. Resource utilisation and cost analysis of memantine in patients with moderate to severe Alzheimer's disease. Pharmacoeconomics. 2003;21(5):327-40. [pmid: 12627986].
432 Brookmeyer R, Johnson E, Ziegler-Graham K, et al. Forecasting the global burden of Alzheimer's disease. Alzheimers Dement. 2007;3(3):186-91. [pmid: 19595937].