# Methods

## Introduction

In this chapter, we document the procedures used by the Duke Evidence-based Practice Center (EPC) to develop this comprehensive evidence report on the factors associated with Alzheimer’s disease (AD) and cognitive decline. To provide a context for the review, we first present the key questions and analytic framework. Next we describe the methods used to identify articles relevant to our key questions, our inclusion/exclusion criteria, and the process we used to abstract relevant information from eligible articles and generate our evidence tables. We discuss our criteria for evaluating the quality of individual articles and synthesizing the evidence. Finally, we describe the peer review process.

## Key Questions

This report addresses risk factors and potential therapeutic interventions that may modify the risk of AD or cognitive decline. A National Institutes of Health (NIH) Office of Medical Applications of Research (OMAR) State-of-the Science Conference planning committee developed the key questions and specified the populations and factors to be evaluated. The specific factors and interventions to be reviewed were refined with input from members of the project’s technical expert panel (TEP), representatives of NIH-OMAR, and staff at the Agency for Healthcare Research and Quality (AHRQ). Although a large number of factors are considered, the report is not inclusive of all factors that have been associated with AD or cognitive decline.

The key questions considered are:

Key Question 1: What factors are associated with the reduction of risk of Alzheimer’s disease?

Key Question 2: What factors are associated with the reduction of risk of cognitive decline in older adults?

Key Question 3: What are the therapeutic and adverse effects of interventions to delay the onset of Alzheimer’s disease? Are there differences in outcomes among identifiable subgroups?

Key Question 4: What are the therapeutic and adverse effects of interventions to improve or maintain cognitive ability or function? Are there differences in outcomes among identifiable subgroups?

Key Question 5: What are the relationships between the factors that affect Alzheimer’s disease and the factors that affect cognitive decline?

Key Question 6: If recommendations for interventions cannot be made currently, what studies need to be done that could provide the quality and strength of evidence necessary to make such recommendations to individuals?

For all questions, we were interested in adults age 50 or older drawn from general populations. For Key Questions 1 and 2, we examine all the risk factors from an epidemiologic standpoint, limiting our review to observational studies and focusing on factors that are not amenable to randomization (e.g., hypertension). For Key Questions 3 and 4, we prioritized randomized controlled trials (RCTs), but because the evidence was often sparse or limited to select samples, we supplemented trial data with evidence from observational studies, where necessary. For Key Question 5, we were interested in the consistency of findings for each exposure/intervention on risk of AD and cognitive decline.

The exposures/interventions evaluated are listed in Table 1.

Table 1 Exposures/interventions evaluated in this report

Factors examined for Key Questions 1, 2, and 5 | Factors and interventions examined for Key Questions 1, 2, 3, 4, and 5
Medical:; A. Vascular factors:; - Diabetes mellitus; - Metabolic syndrome; - Hypertension; - Hyperlipidemia; - Homocysteine; B. Other medical factors; - Sleep apnea; - Obesity; - Traumatic brain injury; C. Psychological and emotional health; - Depression; - Anxiety; - Resiliency; Social/economic/behavioral:; A. Early childhood factors (e.g., early life environment, rural/urban upbringing); B. Education/occupation/IQ/intelligence; C. Tobacco/nicotine use; D. Alcohol use; Toxic environmental exposures, including pesticides, pollution, Gulf War Syndrome, and Agent Orange exposure Genetics | Nutritional and dietary factors:; A. B vitamins and folate; B. Other vitamins; C. Gingko biloba; D. Omega-3 fatty acids; E. Other fats; F. Trace metals; G. Mediterranean diet; H. Fruit and vegetable intake; I. Total intake of calories, carbohydrates, fats, and proteins; Prescription and nonprescription drugs:; A. Statins; B. Antihypertensives; C. Anti-inflammatories; D. Gonadal steroids; E. Cholinesterase inhibitors; F. Memantine; Social/economic/behavioral factors:; A. Social engagement (social network size, social support, and marital status); B. Cognitive engagement (including games, puzzles, and cognitive training); C. Physical activities; D. Other (non-cognitive, non-physical) leisure activities

## Analytic Framework

Our analytic framework (Figure 1) describes the progression from normal cognition to the initiation of subclinical pathophysiological processes to cognitive decline that is beyond what is expected for normal aging and to AD. Although there is a potential for primary prevention prior to the initiation of pathophysiological processes leading to cognitive decline, there are currently not well-validated methods to measure these processes in the absence of cognitive decline. Therefore, we did not consider effects of the candidate factors on changes in pathophysiological processes. The figure shows the potential for treatment interventions to effect cognitive decline and the risk for AD.

Figure 1 Analytic framework

## Literature Review Methods

### Inclusion/Exclusion Criteria

After discussion with the TEP, we generated a list of article inclusion and exclusion criteria (Table 2) for the Key Questions. Because of the large number of factors and interventions to review, we searched initially for good quality systematic reviews. We included primary literature to update eligible reviews or when good quality reviews were unavailable. We limited the primary literature to comparative studies published in English that enrolled adults age 50 years or older at the time of final cognitive assessment, drawn from general populations in economically developed countries. We defined general populations as those drawn primarily from non-institutionalized community settings or general medical populations. With three exceptions, we limited observational studies to longitudinal designs where the risk factor or intervention was measured prior to the outcome. We made exceptions for traumatic brain injury and toxic/environmental exposures because of the difficulties studying these factors longitudinally, and for sleep apnea, because of the absence of cohort studies. Because AD is a relatively uncommon event, we required a sample size greater than 300 to focus on studies with higher statistical power. For similar reasons, we required at least 1 year between exposure and outcomes assessment for studies of cognitive decline, and at least 2 years for studies of AD.

Table 2 Inclusion and exclusion criteria

Category | Criteria
Study population | Humans, all races, ethnicities, and cultural groups KQ 1–6: Adults age ≥ 50 years old; drawn from a general population or general medical setting, with normal cognition or mild cognitive impairment
Study geography | Developed countries: United States, Canada, United Kingdom, Western Europe, Australia, New Zealand, Hong Kong, Japan, Republic of China (Taiwan), Singapore, South Korea, Israel
Factors/interventions | See Table 1, above
Study outcomes | KQ1 & 3: Diagnosis of Alzheimer’s disease using an acceptable standard (e.g., National Institute of Neurological and Communicative Disorders and Stroke and the Alzheimer’s Disease and Related Disorders Criteria) KQ2 & 4: Diagnosis of mild cognitive impairment using an acceptable standard (e.g., Petersen’s criteria) or change in cognition using at least two measurements on an acceptable measure
Outcome timing | KQ1 & 3: At least 1 year after the exposure or intervention KQ2 & 4: At least 2 years after the exposure or intervention
Time period | 1984 to October 27, 2009
Publication languages | English only
Admissible evidence (study design and other criteria) | Good quality systematic reviews that addressed a question of interest and used eligibility criteria consistent with our inclusion/exclusion criteria Original research studies that provide sufficient detail regarding methods and results to enable use of the data and results; relevant outcomes must be able to be abstracted from data presented in the papers. If risk for non-specific dementia only were reported, we required ≥ 60% of the outcomes to be AD. Eligible original research designs include: KQ 3 & 4: Randomized controlled trials (RCTs); KQ 1–4: Observational studies: longitudinal designs comparing exposed to unexposed. For TBI, sleep apnea, and toxic environmental, case-control studies were also eligible. Sample sizes must be appropriate for the study question: RCTs ≥ 50; longitudinal observational ≥ 300

Abbreviations: AD = Alzheimer’s disease; KQ = key question; RCT = randomized controlled trial; TBI = traumatic brain injury

### Literature Search Strategies

Based on the above-described inclusion/exclusion criteria, we generated a list of Medical Subject Heading (MeSH) search terms, supplemented by keyword searches, to search MEDLINE®. Search terms and strategies were developed in consultation with a medical librarian. The exact search strategies used are given in Appendix A. In addition to MEDLINE®, we searched the Cochrane Database of Systematic Reviews to identify relevant systematic reviews. For topics with a recent good quality systematic review (see “Assessment of Methodological Quality,” below), we updated the search by identifying relevant primary literature published from 1 year prior to the search date through October 27, 2009. The 1-year overlap is necessary because of delays between publication in journals and availability for searching in MEDLINE®. Relevant older literature missed or excluded in prior reviews that was relevant and met eligibility criteria was included.

When we did not identify a relevant good quality review, we searched the primary literature to include studies from 1984 through October 27, 2009. Electronic searching was supplemented by examining the bibliographies of reviews and primary studies. Because of the large volume of literature and availability of specialized registries for genetic studies, we developed a separate search strategy for this literature. We examined the HUGE and ALZGene databases to identify relevant systematic reviews for genes identified as being of special interest in consultation with the TEP.

Using the pre-specified inclusion/exclusion criteria, titles/abstracts were examined independently by two reviewers for potential relevance to the key questions. Articles included by either reviewer underwent full-text screening. At the full-text screening stage, two independent reviewers read each article to determine if it met eligibility criteria. Disagreements were resolved by consensus. At the full-text review stage, simple agreement was 84 percent, and median chance corrected agreement was kappa = 0.63 (range 0.40 to 1.0). Articles meeting our eligibility criteria were included for data abstraction.

### Data Abstraction and Data Management

Data from published reports were abstracted into evidence tables by one reviewer and over-read by a second reviewer. Data elements abstracted included descriptors to assess applicability, quality elements, intervention/exposure details, and outcomes. Disagreements were resolved by consensus or by obtaining a third reviewer’s opinion when consensus could not be reached. The final evidence tables are intended to provide sufficient information so that readers can understand the study and determine its quality. Evidence tables for all included studies are presented in Appendix B. Because some studies address more than one exposure or question, the evidence tables are organized alphabetically by author.

### Assessment of Methodological Quality

We developed separate criteria for assessing the methodological quality of included systematic reviews, RCTs, and observational studies. These criteria are given in Appendices C, D, and E, respectively. Briefly, for systematic reviews we assessed the comprehensiveness of the search strategy, the description and appropriateness of inclusion criteria, whether primary studies were assessed for quality and the adequacy of the quality measure, the reproducibility of methods to assess studies, whether the results of relevant studies were combined appropriately, whether heterogeneity and publication bias were assessed, and whether the conclusions were supported by the data presented.

For RCTs, we used the key criteria described in the AHRQ methods manual for Comparative Effectiveness Reviews,24 adapted to this specific topic. These criteria are: adequacy of randomization and allocation concealment; the comparability of groups at baseline; blinding; the completeness of followup and differential loss to followup; whether incomplete data were addressed appropriately; the validity of outcome measures; and conflict of interest.

To assess individual observational studies, we adapted a basic set of quality criteria used in previous AHRQ evidence reports.25,26 These criteria concern the methods used to select the cohort, the adequacy of the sample size, the methods used to ascertain exposure status and outcomes, the adequacy and completeness of followup, and the appropriateness of the analytic methods used. Abstractors assigned a rating of “yes,” “partially,” “no,” or “can’t tell” to each item and provided a brief rationale for their decisions. We did not attempt to assign a summary quality score (“A, B, C” or “Good, Fair, Poor”) to individual RCTs or observational studies because there is no evidence that the use of any particular quality scoring system has a substantial impact on the results of systematic reviews.27 In addition, our experience has been that it is more helpful to identify consistent and specific quality issues that affect the majority of the included studies (concerning, e.g., sample size, analytic methods, or ascertainment bias) in order to guide future research, rather than relying on a global quality score.

We used principles from the Grading of Recommendations Assessment, Development and Evaluation (GRADE) working group (www.gradeworkinggroup.org) to summarize the level of evidence for each factor as low, moderate, or high. The GRADE approach was developed to evaluate the overall level of evidence for interventions, but we have extended the approach to factors (e.g., medical illness) that would not be considered as interventions. The approach considers the body of evidence for each outcome, assigning an initial rating of low quality to observational studies and high quality to RCTs. These initial ratings may be modified by the following factors: detailed study design, consistency, strength of association, dose-response effect, directness, precision, and if all plausible confounding would reduce a demonstrated effect. The resulting judgments about the level of evidence are presented separately in summary tables for AD and cognitive decline in Chapter 5. Judgments about the strength of evidence were made by at least two investigators; final ratings were reached by consensus.

### Data Synthesis

When good quality systematic reviews were identified, we summarize the findings in narrative form in Chapter 3 (“Results”). Any new studies identified since the systematic review was published are summarized descriptively in a table that includes the study sample, exposure classification, duration of followup, adjustment for confounding, and primary outcomes. We evaluated whether the new evidence was likely to change estimates from the prior review by considering the precision and stability of estimates from the original review, the number and size of the new studies relative to studies in the original review, the quality of the new studies, and the consistency in estimates and conclusions between the new evidence and the original review. After considering these issues, we updated prior meta-analyses when substantial new evidence was available and a new summary estimate was likely to lead to different conclusions. We performed primary meta-analysis when studies were conceptually homogeneous and the needed data were available for the summary estimate. Since meta-analysis of observational studies may give spurious precision,28 we applied meta-analysis to observational data only when studies were high quality and conceptually homogeneous (similar subjects, exposure, outcomes).

Synthesizing studies that evaluated cognitive decline was particularly challenging. Cognitive decline can be classified categorically by meeting proposed criteria such as those for mild cognitive impairment (MCI), or by exceeding a threshold on a global cognitive measure such as the Mini-Mental State Examination (MMSE). These categorical outcomes are often more clinically meaningful and therefore were prioritized in this review. Cognitive decline may also be examined using continuous measures of global, isolated, domain-specific measures (e.g., memory, processing speed), or composites of multiple measures for a domain. Many of these measures have not been demonstrated to be responsive to change, and any changes observed may be of uncertain clinical significance. Because of the heterogeneity of the continuous measures reported and the large scope of the present review, we evaluated the relevance of studies reporting continuous measures for each exposure. When there were adequate numbers of studies using categorical outcomes to address the question, we did not provide detailed summaries of the studies reporting continuous outcomes.

## Peer Review Process

Among the more important activities involved in producing a credible evidence report is conducting an unbiased and broadly based peer review of the draft report. External reviewers for this report included clinicians and representatives of professional societies, as well as members of the TEP. The list of nominees was forwarded to AHRQ for vetting and approval. A list of peer reviewers submitting comments on this draft is included in Appendix F.