# Peer Reviewers

The Duke Evidence-based Practice Center is grateful to the following peer reviewers who read and commented on a draft version of this report:

- Jesse Berlin, ScD; Pharmaceutical Research & Development; Johnson & Johnson Pharmaceuticals; Titusville, NJ
- Soo Borson, MD; Department of Psychiatry; University of Washington; Seattle, WA
- Ornit Chiba-Falek, PhD; Institute for Genome Sciences and Policy; Duke University; Durham, NC
- Mary Ganguli, MD, MPH; Department of Psychiatry; University of Pittsburgh; Pittsburgh, PA
- Tiffany Hughes, PhD, MPH; Department of Psychiatry; University of Pittsburgh; Pittsburgh, PA
- Dan Kaufer, MD; Department of Neurology; University of North Carolina; Chapel Hill, NC
- Eric B. Larson, MD, MPH, MACP; Group Health Research Institute; Seattle WA