# Quality Assessment – Observational Studies

General instructions: Grade each criterion as “Yes,” “No,” “Partially,” or “Can’t tell.” Factors to consider when making an assessment are listed under each criterion. Where appropriate (particularly when assigning a “No,” “Partially,” or “Can’t tell” score), please provide a brief rationale for your decision (in parentheses) in the evidence table. Criteria marked italics are considered the most essential quality indicators for our purposes.

1. Unbiased selection of the cohort?
  Factors that help reduce selection bias:
  - Prospective study design and recruitment of subjects
  - Inclusion/exclusion criteria
    - Clearly described (especially re: age and cognitive status)
    - Assessed using valid and reliable measures
  - Recruitment strategy
    - Clearly described
    - Relatively free from bias (selection bias might be introduced, e.g., by recruitment via advertisement)
2. Selection minimizes baseline differences in prognostic factors?
  Factors to consider:
  - Was selection of the comparison group appropriate?
    Note: This may not be an issue in the cohort studies we review. In general, the exposed and unexposed groups should be from the same source. However, it is possible that for some medical condition exposures the exposed group will be patients from a specialty medical clinic and the unexposed comparison group will be from another source. Consider whether these two sources are likely to differ on factors related to the outcome (besides the exposure factor).
  - In addition to selecting the cohort in an unbiased way, did study investigators do other things to ensure that exposed/unexposed groups were comparable, e.g., by using stratification, matching, or propensity scores?
3. Sample size calculated/5% difference?
  Factors to consider:
  - Did the authors report conducting a power analysis or describe some other basis for determining the adequacy of study group sizes for the primary outcome(s) of interest to us?
  - Was the sample size sufficiently large to detect a clinically significant difference of 5% in event rates or an OR/RR increase of ≥ 1.5 or decrease of ≥ 0.67 between groups in at least one primary outcome measure of interest to us?
4. Adequate description of the cohort?
  Consider whether the cohort is well-characterized in terms of baseline:
  - Age
  - Sex
  - Race
  - Educational level
  - Cognitive status
  - For genetic association studies, were the diseased and non-diseased populations drawn from groups with the same ethnic/racial mix?
5. Validated method for ascertaining exposure?
  Factors to consider:
  - Was the method used to ascertain exposure clearly described? (Details should be sufficient to permit replication in new studies.)
  - Was a valid and reliable measure used to ascertain exposure? (Subjective measures based on self-report tend to have lower reliability and validity than objective measures such as clinical reports and lab findings.)
  - For gene association studies, is the “call rate” of genotyping (the proportion of samples in which the genotyping provides an unambiguous reading) reported? Were quality checks implemented or rules established to determine when genotyping results would be considered valid?
  To clarify your score, please make a note of the method/measure used to ascertain exposure.
6. Validated method for ascertaining clinical outcomes?
  Factors to consider:
  - Were primary outcomes (AD and/or cognitive decline) assessed using valid and reliable measures? (See details below.)
  - Were these measures implemented consistently across all study participants?
7. Outcome assessment blind to exposure?
  - Were the study investigators who assessed outcomes blind to the intervention or exposure status of participants?
8. Adequate follow-up period?
  Factors to consider:
  - Minimum adequate follow-up period is 2 years for AD and 1 year for cognitive decline
  - Follow-up period should be the same for all groups
    - In cohort studies, length of follow-up should be the same across all groups.
    - In nested case-control studies, period between the intervention/exposure and outcome should be the same for cases and controls.
    - OK if differences in follow-up time were adjusted for using statistical techniques, e.g., survival analysis.
9. Completeness of follow-up?
  Factors to consider:
  - Did attrition from any group exceed 30%? (Attrition is measured in relation to the time between baseline/allocation and outcome measurement. Where different numbers of patients are followed up for different outcomes, use the number followed up for the primary outcome for this calculation.)
  - Did attrition differ between groups by more than 10% percent?
10. Analysis controls for confounding?
  Factors to consider:
  - Did the analysis control for any baseline differences between groups?
  - Does the study identify and control for important confounding variables and effect modifiers? (Confounding variables are risk factors that are correlated with the intervention/exposure and outcome and may therefore bias the estimation of the effect of intervention/exposure on outcome if unmeasured. Effect modifiers are not correlated with the intervention/exposure, but change the effect of the intervention/exposure on the outcome. Age, race/ethnicity, education, and measures of SES are examples of effect modifiers and confounding variables for the exposures and outcomes of interest in this study.)
11. Analytic methods appropriate?
  Factors to consider:
  - Was the kind of analysis done appropriate for the kind of outcome data?
    - Dichotomous – logistic regression, survival
    - Categorical – mixed model for categorical outcomes
    - Continuous – ANCOVA, mixed model
  - Was the analysis done on an intention-to-treat basis? (That is, was the impact of loss to follow-up [or differential loss to followup] assessed, e.g., through sensitivity analysis or another intent-to-treat adjustment method?
  - Was the number of variables used in the analysis appropriate for the sample size? (The statistical techniques used must be appropriate to the data and take into account issues such as controlling for small sample size, clustering, rare outcomes, multiple comparison, and number of covariates for a given sample size. The multiple comparisons issue may be a problem particularly when performance results on numerous cognitive measures are being compared. When assessing change on cognitive measure over time, consider whether change score should be adjusted for baseline score, and consider distribution of baseline scores and change scores.)
  - For gene association studies:
    - Did the investigators conduct statistical tests to check whether the observed genotype frequencies are consistent with the Hardy-Weinberg Equilibrium?
    - Did the investigators adjust for multiple comparisons?

## Detailed guidance for Item 6 – assessment of AD/cognitive outcomes

### Principles for an acceptable criterion standard for diagnosis of AD

1. Uses established diagnostic criteria (e.g., DSM-IV, NINCDS-ADRDA, ICD or similar).
2. Uses an acceptable method for obtaining the necessary data to apply the diagnostic criteria, defined as an in-person assessment using an assessment battery that addresses the key domains in the diagnostic criteria, namely, at least memory plus one or more of the following: orientation, agnosia, aphasia, apraxia, executive function, or effect on functional status. If the diagnosis is from medical records only, need evidence that a formal in-person evaluation was done to determine the diagnosis of AD.
3. Pathological specimens alone are not satisfactory since AD is a clinical diagnosis. If AD is diagnosed using an acceptable criterion standard, then pathological specimens could provide useful supplementary information.

### Principles for an acceptable criterion standard for diagnosis of cognitive decline

1. An agreed upon set of diagnostic criteria for a categorical diagnosis (e.g., MCI, CIND, or similar as described in text). The diagnostic criteria will vary across studies, but each study should provide details of the criteria used for MCI, CIND, or similar diagnostic terms for mild cognitive symptoms. The definition should include mild cognitive impairment reported by the individual or informant that did not meet criteria for dementia, [underlined: or] performance on neuropsychological measures that was both below expectation and considered to be in the impaired range based on normative standards.
2. An acceptable method for obtaining the necessary data to apply the diagnostic criteria, defined as an in-person assessment using an assessment battery that addresses the key domains in the diagnostic criteria, namely, at least memory plus one or more of the following: orientation, agnosia, aphasia, apraxia, executive function, and evidence that cognitive impairment does not significantly interfere with functional status. If the diagnosis is from medical records only, need evidence that a formal in-person evaluation was done to determine the diagnosis of mild impairment.
3. If cognition is assessed at two or more time points, then change on a validated instrument.