# Quality Assessment – Systematic Reviews^*^ * Adapted from Marinopoulos et al., 2007^1^ and Moher et al., 1999.^2^

For reviews, first determine whether it is a systematic review (SR). To be a systematic review, it must include a methods section that describes (1) a search strategy and (2) an a priori approach to synthesizing the data. For reviews determined to meet the SR criteria, assess methodological quality.

## General instructions

Step 1: Grade each of the criteria listed below as “Yes,” “No,” “Partially,” or “Can’t tell.” Factors to consider when making an assessment are listed under each criterion. Where appropriate (particularly when assigning a “No,” “Partially,” or “Can’t tell” score), please provide a brief rationale for your decision (in parentheses).

1. Is a focused clinical question clearly stated?
  a. At a minimum, question should clearly identify population and outcomes
  b. Does not have to be in PICO format (Population, Intervention, Comparisons, Outcomes)
2. Are the search methods used to identify relevant studies clearly described?
  a. Search methods described in enough detail to permit replication
3. Was the search for evidence reasonably comprehensive?
  a. Search included MEDLINE and other appropriate databases
4. Are the inclusion/exclusion criteria used to screen primary studies clearly described?
  a. Inclusion/exclusion criteria described in enough detail to permit replication
5. Were the inclusion/exclusion criteria appropriate (aimed at avoiding bias in the included studies)?
  a. Criteria likely to capture all relevant studies (consider especially criteria related to study population, risk factor/intervention, outcomes, and study design)
6. Were the primary studies assessed for quality using clearly stated criteria?
  a. Quality assessment was done, and criteria used to assess study quality were specified in enough detail to permit replication
7. Was the quality assessment done appropriately?
  a. Quality assessment was performed using a validated instrument (with citation), or the authors demonstrated the validity of their methods.
8. Were the methods used to assess primary studies reproducible?
  a. Did two or more raters make inclusion/exclusion decisions, abstract data, and assess study quality – either independently or with one over-reading?
  b. Was an appropriate method used to resolve disagreements?
9. Did the authors discuss whether any variation observed in the results of the primary studies might be due to differences in study design or population?
  a. Text or tables provide comparative information on most of following: study design, populations, interventions, and outcome measures
  b. Authors discuss possible sources of heterogeneity
10. Were the results of the relevant studies combined appropriately?
  a. Some assessment of qualitative or quantitative assessment heterogeneity of study results
  b. Accepted qualitative or quantitative method of pooling used (i.e., more than simple addition; e.g., random-effects vs. fixed-effect model for quantitative data)
11. Was publication bias assessed?
  a. Publication bias tested for using funnel plots, test statistics, or search of trials registry for unpublished studies.
12. Are the stated conclusions supported by the data presented?

Step 2: Rate the overall quality of the SR as “Good,” “Fair,” or “Poor” using the guidance below.

Good = After considering items 1–11, item 12 is rated “Yes” with no important limitations. This means that few of the items 1–11 are rated “Partially” or “No,” and none of the limitations are thought to decrease the validity of the conclusions.

Fair = After considering items 1–11, item 12 is rated “Yes,” but with at least some important limitations. This means that enough of the items 1–11 are rated “Partially” or “No” to introduce some uncertainty about the validity of the conclusions.

Poor = After considering items 1–11, item 12 is rated “No.” This means that several of items 1–11 are rated “Partially” or “No,” introducing serious uncertainty about the validity of the conclusions.

## References

1 Marinopoulos S, Dorman T, Ratanawongsa N, et al. Effectiveness of Continuing Medical Education. Evidence Report/Technology Assessment No. 149 (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. 290-02-0018.) AHRQ Publication No. 07-E006. Rockville, MD. Agency for Healthcare Research and Quality. January. 2007. Available at http://www.ahrq.gov/clinic/tp/cmetp.htm. Accessed on September 29, 2009.
2 Moher D, Cook DJ, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. 1999;354(9193):1896-900. [pmid: 10584742].