# Evidence Tables

Study | Study Information | Participants | Risk Factor and Outcome Assessment | Results | Comments/Quality Scoring
Aartsen, Van Tilburg, Smits, et al., 2005 Longitudinal Aging Study of Amsterdam (LASA) | Geographical location: Netherlands Setting: Community Study design: Prospective cohort Number of participants enrolled: 3105 participants enrolled for T1 of LASA. (Oversampled for men and older participants) 1144 participants enrolled for this analysis. Duration of follow up: 6 years. Time from risk factor assessment to final cognitive assessment: 6 years. | Age: Range: 60–85 Sex: [n (%)] Female: 474 (41.43) Male: 690 (58.57%) Race/ethnicity: [n (%)] NR Baseline cognitive status: All Inclusion criteria: Age >60 yrs Married at baseline Exclusion criteria: NR | Risk factor/exposure 1: Loss of spouse during the follow up period (1992–1998) Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Physical health at baseline Mental health at baseline. Method(s) of assessing cognitive status: Other – Recall of 15 words from the Auditory verbal learning test. Informant interview?: No | 1) Follow-up rate: 3805 participants recruited in the first sample which was collected for a different study. Of this, 3107 participated in the T1 phase of the LASA study. Of the 698 who did not participate, 126 (18%) dies, 134(19%) were too disabled to participate, 394 (56%) refused and 44 (6%) could not be contacted. 2545 (82%) participated in T2 and 2076 (67%) participated in T3. Of the participants in T1, 1144 met the inclusion criteria to be included in this analysis. 2) Important baseline differences: Attrition of the sample was related to lower memory at baseline, being male, having chronic diseases or having lower functional ability. 3) Outcome of interest #1: Memory decline was observed in 33% of the widowed men and 17% of the widowed women while one 17% of the non widowed men and 13% of non widowed women had memory decline. There was a statistically significant difference between widowed and non widowed men: χ^2^= 6.6; p<0.05 but not for women χ^2^= 2.3; p=0.13. | Comments: There were some baseline differences between the participants who were lost to follow up and those included in this analysis. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: Can’t Tell 4) Adequate description of the cohort?: No 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Can’t Tell 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes.
Abbott, White, Ross, et al., 2004 Honolulu Heart Program, Honolulu- Asia Aging Study (HAAS) | Geographical location: Honolulu, Hawaii Setting: Community Study design: Prospective cohort Number of participants enrolled: Initially 3734; Final sample of 2257. Duration of follow up: Mean “nearly” 7 years Time from risk factor assessment to final cognitive assessment: Mean “nearly” 7 years | Age: Mean (SD): Miles walked/day: <0.25: 77.4 (4.4) 0.25–1: 77.3 (4.2) <1–2: 76.6 (3.8) >2: 76.0 (3.6) Sex: Female: 0% Male: 100% Race/ethnicity: Japanese ancestry Baseline cognitive status: Non-demented Inclusion criteria: Survivors of the original Honolulu Heart Program cohort. Japanese ancestry. Men physically capable of exercise, as defined by having presented for a baseline clinical exam and reported slight or moderate activities in a24-hour period. Exclusion criteria: Prevalent dementia. Poor cognitive function whose dementia status could not be confirmed. Prevalent Parkinson’s disease or stroke. Subjects with missing data on physical activity. Continued employment. Daily activities failed to meet criteria for being slight or moderate. Smokers. Use of walker or cane. | Risk factor/exposure 1: Physical activity, specifically walking Method of assessing risk factor/exposure 1: Self report. “Participants were asked about the average amount of distance walked per day.” Other--Physical Activity Index (referenced in paper, but not described, other than saying it is a common measure of daily metabolic output). Also assessed physical function at baseline via battery of test, for a “physical performance score.” Covariates/potential confounders adjusted for in analyses: Age; APOE; Baseline CASI; Declines in activity since mid adulthood Method(s) of assessing cognitive status: Initial screening with CASI <74. 3 screening phases. NINCDS-ADRDA DSM IIIR Other: Informant Questionnaire on Cognitive Decline in the Elderly Informant interview?: Yes | 1) Follow-up rate: 2257 out of 3734 (60.4%). Initial Honolulu Heart Program had 8006 men. 3734 of survivors initially potentially eligible for this study. Excluded from f/u: men who died(n=377), prevalent dementia (n=145), poor cognitive function (n=75) whose dementia status couldn’t be confirmed, Parkinsons (n=39), prevalent stroke (n=116), missing data on physical activity (n=194), failed to present for a clinic visit(n=112), no slight or moderate activity (n=76), smokers (n=161), use of walker or cane (n=27). 2) Important baseline differences: NA 3) Outcome of interest #1 Incidence of dementia: 158(15.6/1000 person-years). Among these, 101 (10.0/1000 person-yrs) were attributed to AD and 30 (3.0/1000 p-y) attributed to vascular dementia as sole or primary cause. 27 cases (2.7/1000 prs-yrs) with mixed AD and other dementia. Median time from baseline exam to Dx was 4.7 yrs (range: 2.4–7.4). 4) Outcome of interest #2-- Dementia Men who walked the least (<0.25 mile/d) experienced a 1.8 fold excess of total dementia compared to those who walked the most (> 2 mile/d). Compared with men who walked the most (> 2 mile/d), an excess of dementia was observed in those who walked 0.25 to 1 mile/d (17.6 vs. 10.3/1000 person-yrs; RH, 1.71; 95% CI, 1.02–2.86). (RH = relative hazard) After adjusting for covariates, a 1.9-fold excess risk of total dementia was found in me who walked less than 0.25 mile/d compared to those who walked > 2 mile/d (RH, 1.93; 95% CI, 1.11–3.34). Compared with the most active men, those who walked 0.25to 1 mile/d experienced a 1.7-fold excess in dementia risk (RH, 1.75; 95% CI, 1.03–2.99). 5) Outcome of interest #3—Alzheimer’s Disease There was an 1.8-fold excess of AD in men who walked 2 mile/d or less vs. those who walked more than 2 mile/d. An association between walking and vascular dementia was less apparent. After adjusting for covariates, risk of AD was 2.2-fold higher in men who walked the most (RH, 2.21; 95% CI, 1.06–4.57). 6) Outcome of interest #4—Timed walk “The focus of this report is on day-to- day activity; however, a faster timed walk at baseline eval was also associated with a decreased age- adjusted incidence of dementia.” | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Partial 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
ADAPT Research Group, 2007 | Geographical location: Baltimore, MD Boston, MA Rochester, NY Seattle, WA Sun City, AZ Tampa. FL Setting: Community Study design: RCT Test intervention: Celecoxib 200mg BID OR Naproxen Sodium 220mg BID Comparator intervention(s): Placebo Number of participants enrolled: 2528 Duration of follow up: ~735 days Time from risk factor assessment to final cognitive assessment: RCT with annual cognitive screening Time varied because of termination of trial –75th percentile ~830 days | Age: Mean (SD): 74 Range: 70–90 Sex: [n (%)] Female: 1160 (45.9%) Male: 1368 (54.1%) Race/ethnicity: [n (%)] White, non-Hispanic 2452 (97%) African-American 38 (1.5%) Hispanic 18 (0.7%) Other 20 (0.8%) Baseline cognitive status: Non-demented For MCI analyses baseline status excluded those with prevalent MCI/PrAD But all have first degree relatives with AD Inclusion criteria: ≥ 70 yo; h/o at least 1 first degree relative w/Alzheimer-like dementia; aspirin use of ≤ 81 mg/day allowed Exclusion criteria: Regular use of NSAIDS | Risk factor/exposure 1: nsaid Method of assessing risk factor/exposure 1: RCT with naproxen, celecoxib, placebo Covariates/potential confounders adjusted for in analyses: Randomization stratified by age group, field site Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Informant interview?: Yes | 1) Follow-up rate: 83-5% follow up but nearly half “terminated drug” 2) Important baseline differences: p’s not given, nothing looks obvious 3) Outcome of interest #1: Neither tx associated with a decreased risk of AD. 4) Outcome of interest #2: HR for possible increased risk of AD celecoxib 4.11 (1.3–13), naproxen 3.57 (1.09–11.7) | Comments: Study terminated bec of cox II. Almost half of subjects “terminated” drug Quality assessment: For RCTs: 1) Baseline comparability?: Yes 2) Valid AD/cognitive outcomes assessment?: Yes 3) Subjects/providers blind?: Yes 4) Outcome assessors blind?: Partial 5) Incomplete data adequately addressed?: No 6) Differential dropout rate <10%?: Yes 7) Overall dropout rate < 30%?: No 8) Conflict of interest reported and insignificant?: Yes 9) Randomization adequate?: Yes 10) Allocation concealment adequate?: Yes
Aggarwal, Bienas, Bennett, et al., 2006 CHAP Study | Geographical location: 3 southside Chicago neighborhoods(Morgan Park, Washington Heights, & Beverly) Setting: Community Study design: Prospective cohort Number of participants enrolled: 6158 Duration of follow up: mean 4.1 (range 0.4 –6.9) Time from risk factor assessment to final cognitive assessment: mean 4.1 (range 0.4–6.9) | Age: Mean (SD): 73.1 Range: ≥ 65 Sex: [n (%)] Female: 61.9% Male: 38.1% Race/ethnicity: [n (%)] AA 49.8% Other 50.2% Baseline cognitive status: Non-demented Inclusion criteria: ≥ 65 yo; institutionalized residents included Exclusion criteria: NR | Risk factor/exposure 1: Smoking Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Freq participation in cog act. APOE Time from baseline to cog eval Method(s) of assessing cognitive status: NINCDS-ADRDA Informant interview?: No | 1) Follow-up rate: 1064/1527 (69.7%) 2) Important baseline differences: NR 3) Outcome of interest #1: Current smokers at greater risk of AD than never smokers Former smokers not at greater risk of AD than non-smokers (Ever smoked vs never smoke did not show increased risk of AD for smoking) 4) Outcome of interest #2 Current smokers, no e4 – increased risk of AD Former smoker, e4 – reduced risk of AD 5) Outcome of interest #3 Current smokers, pack yrs did not assoc with risk Former smokers, as pack years increased, AD risk decreased | Comments: For Q1 Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Can’t Tell 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Partial 7) Outcome assessment blind to exposure?: Can’t tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Can’t tell 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Akbaraly, Hininger- Favier, Carriere, et al., 2007 EVA Study | Geographical location: Nantes district, France Setting: Community Study design: Prospective cohort Number of participants enrolled: 702 completed 9 waves of data collection (Numbers vary by analyses, but this seems to be the maximum in any analyses). Duration of follow up: 9 yrs Time from risk factor assessment to final cognitive assessment: 9 yrs from baseline, but risk factor collected each wave also. Analyses looked at parallel change in risk factor level and cognitive performance | Age: Mean (SD): 65 (3.0) yrs Sex: [n (%)] Female: 436 (62.1) Male: 266 (37.9) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented – this is not stated but is assumed. Only those that were followed for 9 yrs were included in the analyses, so it is likely that anyone demented at baseline would have been able to still do the cognitive tests 9 yrs later. Inclusion criteria: Born between 1922–1932 Living in Nantes district of France Recruited from electoral rolls and information campaigns When ind enrolled automatically asked spouse to participate. Exclusion criteria: None | Risk factor/exposure 1: selenium Method of assessing risk factor/exposure 1: Direct measurement Covariates/potential confounders adjusted for in analyses: Sex Educational level Time period of observation Baseline plasma selenium level Diabetes Hypertension Dyslipidemia Hx of cardiovascular disease Method(s) of assessing cognitive status: Other – cognitive decline on multiple measures using both continuous change as outcome and dichotomous outcomes using two cutoffs (25^th^ and 10^th^ percentiles of change) The analytical approach(mixed models) takes into account the baseline score Informant interview?: No | 1) Follow-up rate: 702/1288 (denominator excludes those who did not complete fup due to death) 2) Important baseline differences: NR reported by exposure group 3) Outcome of interest #1 9-yr change in selenium was associated with 9 yr continuous change in MMSE only (CI=0.12–0.62). It was not significant for other cognitive measures. 4) Outcome of interest #2 Change in selenium during the 1^st^ 2 years of the study was not associated with cognitive change in years 1–9 of the study 5) Outcome of interest #3 Using the categorical cognitive decline measure, cognitive decline at either the 25^th^ or the 10^th^ percentile was significant for MMSE, DSS, TMTB (but not at both cut points). Only FTT was significant at both impairment cut points. | Comments: Question 2 Did not covary for age at baseline because it was not sig associated with change in cognition Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Partial, recruited from electoral rolls and advertisement 2) Selection minimizes baseline differences in prognostic factors?: Partial 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t tell, but probably yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Akbaraly, Portet, Fustinoni, et al., 2009 3 City Study | Geographical location: Dijon (n=4931) Montpelier (n=2259) France Setting: Community 1999–2001 Study design: Prospective cohort Number of participants enrolled: 5692 Duration of follow up: 4 yr Time from risk factor assessment to final cognitive assessment: 4 yr | Age: Mean (SD): 73.7(SDNR) Range: ≥65 Sex: [n (%)] Female: 3468 (60.9%) Male: 2238 (39.1%) Race/ethnicity: [n (%)]NR Baseline cognitive status: Non-demented Inclusion criteria: ≥ 65 Had both F/U appts leisure activity Ques Complete baseline information Exclusion criteria: dementia | Risk factor/exposure 1: 16 leisure activities at baseline, categorized as stimulating, passive, physical or social and analyzed by tertiles Method of assessing risk factor/exposure 1: 2 Self-report Ques. Daily with 3 pt scale Monthly with 4 pt scale Covariates/potential confounders adjusted for in analyses: Age Sex Study center (Dijon or Montpelier) Marital status Educational level Occupational grade Health status – Vascular risk factors Diabetes HTN High cholesterol Hx of CVD Depressive sx CES-D > 16 Physical fx AODL (score > 0) Cognitive impairment MMSE (score <24) APOE genotype Method(s) of assessing cognitive status: 3-step process: Neuropsych tests Individual assessment Committee review using NINCDS-ADRDA And DSM-IV criteria Informant interview?: No | 1) Follow-up rate: 92.3% of cohort had F/U data This was a retrospective analysis of prospectively collected data 2) Important baseline differences: Participants varied on numerous socio-demographic and clinical factors across the tertiles of leisure activities 3) Outcome of interest #1 All cause dementia over time (161 new cases over 4 y) Stimulating activities related to reduced risk: HR = 0.46, CI=0.27/0.80; independent of other proxies for CR, vascular disease risk factors, and other leisure activities BUT if control for cognitive impairment at baseline as well as health status, CI includes one and association is now a trend 4) Outcome of interest #2 Alzheimer’s Disease over time (105 new cases over 4 y) Stimulating activities related to reduced risk: HR = 0.50, CI=0.33/0.78; independent of other proxies for Cognitive Reserve, vascular disease risk factors, and other leisure activities BUT if control for cognitive impairment at baseline as well as health status, CI includes one and association becomes trend 5) Outcome of interest #3 In the most adjusted model, the HR for AD by tertile was: Stimulating leisure activities High: 0.39 (0.21–0.71) Mild: 0.45 (0.26–0.77) Ref Passive leisure activities: High: 0.68 (0.41–1.13) Mild: 1.02 (0.62–1.69) Ref Physical leisure activities: High: 1.29 (0.80–2.09) Mild: 0.87 (0.50–1.51) Ref Social leisure activities: High: 0.70 (0.41–1.21) Mild: 1.06 (0.67–1.68) Ref In a sensitivity analysis excluding those with low MMSE at baseline, then those with incident AD at 1^st^ follow-up, then those with MCI at baseline, stimulating leisure activities remained associated with a lower risk of AD | Comments: Question 1 Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Partial, didn’t include baseline MCI differences until last analysis 3) Sample size calculated/5% difference?: Can’t Tell 4) Adequate description of the cohort?: Partial, race not given 5) Validated method for ascertaining exposure?: No, scales not validated; 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes, 11) Analytic methods appropriate?: Partial – association between leisure activity and risk of dementia over time was tested by proportional hazards model (time scale was age and entry point). Interactions were tested BUT poor measurement of risk was further compounded by making scale into tertiles simply because distribution of results was non-normal. Non-normal distribution of some of the activities would be expected. Were outliers tested? Was data examined as continuous variable with and without outliers and compared to see if results the same? Not done or data not shown.
Akomolafe , Beiser, Meigs, et al., 2006 Framingham Study | Geographical location: Framingham, Massachusetts, USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 2210 Duration of follow up: 12.7 years Time from risk factor assessment to final cognitive assessment: Varies. Diabetes was assessed at each of the biennial exams. | Age: Mean (SD): 70 years (7.0) Sex: [n (%)] Female: 1325 (60%) Male: 885 (40%) Race/ethnicity: NR Baseline cognitive status: Normal Non-demented Inclusion criteria: Participants in the Framingham study Not demented Exclusion criteria: MCI or dx as having dementia | Risk factor/exposure 1: Diabetes mellitus Method of assessing risk factor/exposure 1: Self-report Direct measurement Medical record Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Baseline cognitive status Total homocysteine Smoking Alcohol BP Cardiovascular risk factors Stroke Method(s) of assessing cognitive status: NINCDS-ADRDA Informant interview? Can’t tell | 1) Follow-up rate: 2210/2611= 84.6% 2) Important baseline differences: DM>control Male Sex, systolic BP, BMI, stroke, other cardiovascular risk factors Control>DM Education >12 years, <2 alcoholic drinks/day 3) Outcome of interest #1 17 of 202 persons with DM (8.4%) and 220 of 2008 persons without DM (11.0%) developed AD RR 1.15 (95% confidence interval, 0.65–2.05). 4) Outcome of interest #2 Among subjects without an apolipoprotein E □4 allele or elevated plasma homocysteine levels, 44 of 684 persons (6.4%) developed AD. RR diabetics with nondiabetics 2.98 (95% confidence interval, 1.06– 8.39; P=.03). Age >75 years and DM RR incident AD 4.77 (95% confidence interval, 1.28– 17.72; P=.02). | Comments: Results may be effected by baseline differences in other risk factors that could be associated with AD Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Alvarado, Zunzunegui, Del Ser, et al., 2002 Aging in Leganes Study | Geographical location: Leganes, Spain Setting: Community Study design Prospective cohort Number of participants enrolled: 964 enrolled 557 completed follow up Duration of follow up: 4 years Time from risk factor assessment to final cognitive assessment: 4 years | Age: Range: 65–89 yrs old Sex: Female: 294(52.7%) Male: 263(47.3%) Race/ethnicity: NR Baseline cognitive status: Non-demented Inclusion criteria: At least 65 yrs old, living at home, without severe cognitive impairment or visual impairment, low educational level (without primary school completion) Exclusion criteria: Severe cognitive deficit (92 subjects excluded) Visual impairment (unable to see 23-point characters)(102 subjects excluded) | Risk factor/exposure 1: educational attainment Method of assessing risk factor/exposure 1: Self-report 1) illiterate 2) literate (no formal educ, can read and write) 3) 1–3 yrs of formal education 4) 4 or more years of formal education Then reclassified into 2 categories: 1) incomplete primary school 2) complete primary school Risk factor/exposure 2: occupation Method of assessing risk factor/exposure 2: Self-report Lifelong occupation, according to the Spanish National Classification of Occupations 5 categories: 1) white collar and skilled workers 2) semiskilled 3) unskilled 4) housewives 5) farm workers Reclassified to: 1) farm workers 2) others Method of assessing risk factor/exposure 3: Combined education and occupation. 1) primary school and not farm workers 2) no primary school and farm workers 3) no primary school and not farm workers Method(s) of assessing cognitive status: “Cognitive function assessed via items involving orientation and memory that have been validated for people with low levels of education.” Total cumulative score (range 0–32) at baseline and 4-yr f/u. Both continuous and change scores in 3 categories: 1) “mild decline” = −2 to −7 2) “severe decline” −8 to −23 2) “normal” = −1 to 12 Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Baseline cognitive status Occupation Method(s) of assessing cognitive status: Other – Cognitive decline over 4 years. Short Portable Mental Status Questionnaire (SPMSQ) Informant interview?: No | 1) Follow-up rate: 557/964 = 57.7% 2) Important baseline differences: N 3) Outcome of interest #1 557 subjects completed follow up. Total 176 subjects combined experienced decline: 61 subjects (11%) experienced severe decline (> 1 SD below mean, −8 to −23/32) 115(20.6%) experienced mild decline.(change within 1SD below mean, −2 to −7/32) Less than primary education vs complete primary risk of cognitive decline: OR 1.49(95% CI: 0.92–2.43) Less than primary and farm worker vs complete primary and non-farm worker: OR 2.36(95% CI 1.16–4.81) Less than primary and non-farm worker vs complete primary and non- farm worker: OR 1.39(95% CI: 0.85–2.29) Farm workers vs non-farm workers: OR 1.79 (95% CI: 0.99–3.23) 4) Outcome of interest #2 Authors’ conclusion: “the association of low education level with cognitive decline is supported by our study” among a Spanish population with low levels of formal education | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Partial 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Partial 5) Validated method for ascertaining exposure?: Yes for education, Can’t Tell for occupation 6) Validated method for ascertaining clinical outcomes?: Yes (authors state the method has been validated) 7) Outcome assessment blind to exposure?: No 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: No. attrition exceeded 30% 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Alves de Moraes, Szklo, Knopman, et al., 2002 ARIC Study | Geographical location: Forsyth County, NC Jackson, MS Minneapolis, MN Washington County, MD Setting: Community Study design: Prospective cohort Number of participants enrolled: 8058 Duration of follow up: 6 years Time from risk factor assessment to final cognitive assessment: risk factor assessment done at beginning and end of six year period. Cognitive testing also at both visits. | Age: Mean (SD): 56.7 (5.6) Sex: Female: 51.7% Male: 48.3% Race/ethnicity: White 6342 (78.7%) Other: 1716 (21.3%) Baseline cognitive status: Subjects don’t appear to have been screened on the basis of cognitive functioning. Inclusion criteria: Participating in ARIC Study (Atherosclerosis Risk in Communities) Exclusion criteria: History of stroke or transient ischemic attack in visit 2 and/or visit 4 Taking medications that may affect the central nervous system Missing cognitive test scores in either visit | Risk factor/exposure 1: htn Method of assessing risk factor/exposure 1: Self-report Direct measurement htn defined by self report, use of antihypertensive meds, or sbp ≥140 or dbp ≥ 90. Four categories: nl bp, incident htn, partially controlled htn (one or other visits had nol bps) and uncontrolled htn. Covariates/potential confounders adjusted for in analyses: Age, Race, Sex, Educational level, diabetes Method(s) of assessing cognitive status: change in test score Informant interview?: No | 1) Follow-up rate: 11320/15782 (72%) had both follow up visits. Final n of 8058 by excluding those with strokes, tias, missing cognitive scores, or cns meds 2) Important baseline differences: I see baseline differences between those who followed up and those who didn’t but not between those with and without htn. 3) Outcome of interest #1 In comparing each category of htn to normotensive subjects, the only significant difference was that between uncontrolled hypertensives and normotensives for the DSS score. In data not shown this is limited to inidividuals over the median age of the cohort (>56 yrs at the first visit considered here). | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Partial 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Andel, Crowe, Pedersen, et al., 2008 The HARMONY Study Swedish Twin Registry | Geographical location: Sweden Setting: Community Study design: Case-control design and co-twin control design “Prospective case- control” (i.e., participants in a case- control study in 1967 follow-up in 1998) Number of participants enrolled: 4506 were eligible to be contacted by HARMONY in 1998. 3366 participated in telephone screening and/or w/u for dementia. 3134 in final analysis (includes 655 twin pairs). 70% response rate. Duration of follow up: 31 years Time from risk factor assessment to final cognitive assessment: 31 years | Age: Mean (SD): 48.1 (4.9) at baseline and 79.5 (5.0) at f/u. Sex: Female: 61% Male: 39% Race/ethnicity: NR Baseline cognitive status: Normal Demented Inclusion criteria: All living twins in the STR cohorts of twin pairs who completed a questionnaire in 1967 or 1970 and who underwent dementia assessment in 1998 or later as part of the HARMONY study. HARMONY inclusion criteria include all twins in the STR who were living and 65 years or older in 1998. Controls were selected from the community (including persons in long-term care). Exclusion criteria: NR | Risk factor/exposure 1: Light exercise or hard physical training at midlife Method of assessing risk factor/exposure 1: Self-report: “How much exercise have you had from age 25 to 50?” 0=hardly any 1=light exercise 2=regular exercise 3=hard physical training Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Other—diet, BMI, alcohol, smoking, angina. Also explored lifestyle as a possible effect modifier Method(s) of assessing cognitive status: Two-stages: screen followed by clinical evaluation. “Telephone screening and/or clinical work-up for dementia.” Informant interview? Yes | 1) Follow-up rate: 3134/4506 = 70%. 3366 participated in telephone screening and/or clinical w/u for dementia. 1372 drop outs (who were 1.5 yrs older, more women, fewer high education level, less likely to drink alchohol). Some differences in exercise levels also. 2) Important baseline differences: Cases were older than controls, but the groups did not differ in time of follow-up. 3) Outcome of interest #1 Of 3134, 264 had dementia (176 with AD). 4) Outcome of interest #2 Case-control analysis [underlined: Crude OR] (95% CI), with hardly any exercise as the reference: [underlined: Dementia] light exercise: 0.61 (0.44–.086) regular exercise: 0.21 (0.10–0.45) hard training: 0.78 (0.46–1.30) [underlined: AD] light exercise: 0.62 (0.41–0.93) regular exercise 0.21 (0.09–0.52) hard training: 0.78 (0.46–1.30) No effect modifiers for lifestyle factors were identified. [underlined: Adjusted OR] (95% CI), with hardly any exercise as the reference: [underlined: Dementia] light exercise: 0.63 (0.43–0.91) regular exercise: 0.34 (0.16–0.72) hard training: 0.70 (0.40–1.24) [underlined: AD] light exercise: 0.64 (0.41–1.00) regular exercise 0.34 (0.14–0.86) hard training: 0.65 (0.33–1.29) 5) Outcome of interest #3 Co-twin control analysis “There was a statistical trend indicating that twins who exercised more than their co-twins had reduced odds of dementia in analyses with and without controlling for education.” Adjusted OR for co-twin controls association between exercise and dementia: 0.66 (95% CI: 0.24–1.83) | Comments: Method of assess cognitive status not reported. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: Can’t Tell 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: No 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Partial 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate? Yes
Anonymous, 2002 The Heart Protection Study | Geographical location: 69 UK sites Setting: Clinical – Special, hospital based study clinics Study design: RCT; 2*2 factorial Test intervention: Simvastatin 40mg daily; antioxidant vitamins Comparator intervention(s): Placebo Number of participants enrolled: 20,536 (10,269 intervention; 10, 267 placebo) Duration of follow up: Mean= 5 years Time from risk factor assessment to final cognitive assessment: Mean = 5 years | Age: Range: 40 – 80 years Sex: [n (%)] Female: 5082 (24.7%) Male: 15454 (75.3%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented (no existing diagnosis at baseline; no screening or formal assessment done) Inclusion criteria: Age about 40–80 Total cholesterol >= 135 mg/dl High risk for death from CHD Exclusion criteria: GP determined statin is clearly indicated Chronic liver or renal disease severe CHF inflammatory muscle disease conditions limiting adherence (e.g. dementia or psychiatric disorder) | Risk factor/exposure 1: statin Method of assessing risk factor 1: Direct measurement- calendar packed tablets Method(s) of assessing cognitive status: 1. modified Telephone interview for cognitive status at final follow-up only 2. Dementia – assessment method not specified but appears to be non- study clinician diagnosis Informant interview?: No | 1) Follow up rate: >99% m-TICS score <22/39 at final follow- up: 23.7% simvastatin vs. 24.2% placebo; p=ns Mean m-TICS at final follow-up (unadjusted): 24.08 simvastatin vs. 24.06 placebo; difference between group means = 0.02 [SE 0.07] Incident dementia (dementia/total): 31/10,269 (0.3%) simvastatin vs. 31/ 10267(0.3%) placebo (no p value) | Comments: Poor measures of cognitive change (TICS may not be sensitive to change) Poor assessment for dementia Quality assessment: For RCTs: 1) Baseline comparability? Partial 2) Valid AD/cognitive outcomes assessment? No 3) Subjects/providers blind? Yes 4) Outcome assessors blind? Yes for TICS, uncertain for dementia 5) Incomplete data adequately addressed? Yes 6) Differential dropout rate < 10%? Yes 7) Overall dropout rate < 30%? Yes 8) Conflict of interest reported and insignificant? Yes 9) Randomization adequate? Yes 10) Allocation concealment adequate? Yes
Applegate, Pressel, Wittes, et al., 1994 SHEP study | Geographical location: USA, Multicenter Setting: Community Study design: RCT – double-blind, placebo controlled Test intervention: Chlorthalidone 12.5 or 25mg daily, step 1 – atenolol 25 or 50m mg or reserpine 0.05 or 0.10 mg daily Comparator intervention(s): Matching placebo Number of participants enrolled: 4736 in sample overall; 1993 had detailed cognitive assessment (987 intervention, 1006 control) Duration of follow up: Mean 5 years Time from risk factor assessment to final cognitive assessment: 5 years | Age: Mean (SD): 71.6 (6.7) Sex: [n (%)] Female: 807 (57%) Male: 566 (43%) Race/ethnicity: [n (%)] White non-Hispanic (79.2%) Black 13.85 Hispanic 1.8% Asian 4.3% Other 0.9% Baseline cognitive status: Non-demented Inclusion criteria: Mean SBP 160–219 and DBP <90 mmHg Exclusion criteria: History or signs of major CV disease likely to require pharmacologic and other treatment; other major diseases (e.g., cancer) with competing risk factors for primary endpoint; h/o dementia, alcohol abuse | Covariates/potential confounders adjusted for in analyses: None Method(s) of assessing cognitive status: Other – Short care cognitive assessment; Digit symbol substitution; addition test; findings A’s test; Boston Naming Test; Letter Sets Test; Delayed Recognition Span Test Informant interview?: No | 1) Follow-up rate: 1564/1993 2) Important baseline differences: None 3) Outcome of interest #1 Mean short care cognitive impairment assessment (placebo change minus intervention change) = 0.05 (95% CI −0.0006 – 0.11); intervention declined more but not statistically significant 4) Outcome of interest #2 “There were no significant differences in the mean changes between treatment and control groups for any of the cognitive function tests” (data not given) 5) Outcome of interest #3 Dementia: 37/2365 in intervention group; 44/2371 in control group; OR 0.84 (0.54–1.31) Adverse effect leading to drug discontinuation: intervention group 665/2365, control group 493/2371; OR 1.49 (1.30–1.70) | Comments: None Quality assessment: For RCTs: 1) Baseline comparability?: Yes 2) Valid AD/cognitive outcomes assessment?: Yes 3) Subjects/providers blind?: Yes 4) Outcome assessors blind?: Yes 5) Incomplete data adequately addressed?: Partial 6) Differential dropout rate < 10%?:Yes 7) Overall dropout rate < 30%?:Yes 8) Conflict of interest reported and insignificant?: Can’t Tell 9) Randomization adequate?: Yes 10) Allocation concealment adequate?: Yes
Arvanitakis, Grodstein, Bienias, et al., 2008 Religious Orders Study | Geographical location: Numerous US locations Setting: Community –Religious orders Study design: Prospective cohort Number of participants enrolled: 1019 Duration of follow up: annual follow up from one to 12 years Time from risk factor assessment to final cognitive assessment: Variable because risk factor info collected at each annual assessment. Time between risk factor and final outcome could be between 1 and 12 years follow-up | Age: Mean: 75 yo Sex: [n (%)] Female: 707 (69.4%) Male: 312 (30.6%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Enrolled in Religious Order Study; agree to annual clinical evaluations & brain donation upon death Exclusion criteria: Dementia at baseline | Risk factor/exposure 1: nsaids/asa Method of assessing risk factor/exposure 1: inspection of pill bottles at each assessment Covariates/potential confounders adjusted for in analyses: Age Sex Education, vasc risk factors, E4 Method(s) of assessing cognitive status: NINCDS-ADRDA Other: cognitive change on multiple tests Informant interview?: No | 1) Follow-up rate: 1019/1102 had at least one annual follow-up assessment 2) Important baseline differences: nsaid users, more women, higher sbp. ASA users: older, to be male, more mi’s, more cva’s 3) Outcome of interest #1 Risk of AD not different according to use of nsaid or asa baseline. 4) Outcome of interest #2 nsaids vs not AD 1.19 (0.87–1.62) 5) Outcome of interest #3 ASA vs not AD 0.84 (0.63–1.11) 6) Outcome of interest #4 Cognitive decline on multiple measures was not associated with use of NSAIDS or ASA (p values ranged from 0.14 to 0.77) | Comments: Highly educated sample Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Partial 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Partial 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Arvanitakis, Schneider, Wilson, et al., 2008 Religious Orders Study | Geographical location: Multiple US sites Setting: Community Study design: Prospective cohort Number of participants enrolled: 1011 929 with ≥ 1 yr f/u analyzed Duration of follow up: 1 – 12 yrs (mean NR) Time from risk factor assessment to final cognitive assessment: 1 – 12 yrs | Age: Mean (SD): Group A 72.7 (6.1) Group B 75.2 (7.1) Sex: Female: 638 (69%) Male: 291 (31%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Normal Non-demented Inclusion criteria: “Older Catholic Clergy” Exclusion criteria: Dementia | Risk factor/exposure 1: Statin simvistatin 32 lovastatin 33 atorvastatin 35 pravastatin 12 fluvastatin 5 antidiabetic agents Method of assessing risk factor/exposure 1: Other – medication containers inspected Risk factor/exposure 2: Vascular disease summary score (MI, CHF, claudication, stroke) Vascular risk factor summary score (HTN, diabetes, smoking) Method of assessing risk factor/exposure 2: Self-report Other – clinical exam for stroke Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level In a separate model, they also added vascular risk factors and stroke as covariates. Method(s) of assessing cognitive status: NINCDS-ADRDA Other – change in performance on cognitive tests over time Informant interview?: No | 1) Follow-up rate: 929 of 1011 (91.8%) HR for AD = 0.91 (95% CI 0.54 to 1.52), adjusted for age, sex, education, Analysis that added vascular disease score and vascular risk factor score “did not change this finding” Interaction effects were non-significant for : statins and vascular diseases or risk factors or ApoE e4 Continuous outcome: Statin use associated with change in cognition adjusted for age, sex and education. Regression coefficient, (Standard error), p value Global cognition: −0.014, (0.012,) p=0.245 Episodic memory: −0.017, (0.016), p=0.290 Semantic memory: −0.008, (0.013), p=0.529 Working memory: −0.009, (0.009), p=0.321 Perceptual speed: −0.006 (0.013), p=0.617 Visuospatial ability: −0.009, (0.010), p=0.329 (unsure when f/u assessment was performed) Continuous outcome [see instructions above] | Comments: F/U time is not specified for change in cognition (AD outcomes appear appropriately analyzed, cognitive change may not be); only baseline statin use evaluated Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Partial 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Partial 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Partial 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Atti, Palmer, Volpato, et al., 2008 Kungsholmen Project | Geographical location: Kungsholmen area of Stockholm, Sweden Setting: Community Study design Prospective cohort Number of participants enrolled: 1255 Duration of follow up: 9 years Time from risk factor assessment to final cognitive assessment: 9 years | Age: Mean (SD): 80.8 (4.5) Sex: [n (%)] Female: 925 (73.71%) Male: 330 (26.29) Race/ethnicity: [n (%)] NR Baseline cognitive status: Normal Non-demented Inclusion criteria: All residents of the Kungsholmen area Exclusion criteria: Diagnosis of dementia; Unknown educational level, Baseline MMSE score less than 20, Very old age (≥95) | Risk factor/exposure 1: Obesity Method of assessing risk factor/exposure 1: Direct measurement Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Baseline cognitive status Depressive symptoms Impairment in ADLs Chronic disease at baseline. Method(s) of assessing cognitive status: DSM III (agreement among 3 physicians. If they disagree, patient examined by third) Informant interview?: No | 1) Follow-up rate: 646/1255 *100= 51.47% of those not in the follow-up sample 291 subjects were deceased at follow-up and 189 had incident dementia. Only 170 dropped out and 98 lacked BMI measurement. 2) Important baseline differences: The sample had more women More women were underweight More men had chronic disease at baseline. 3)Outcome of interest #1 Overweight subjects (n575, 22.5%) had a lower risk of developing AD over 9 years of follow-up (HR50.66, 95% CI50.50–0.88), which was confirmed when only incident cases occurring between 6 and 9 years were considered (n 521, 15.3%; HR50.67, 95% CI50.40–1.15) 4) Outcome of interest #2 (The following include all types of dementia) Risk of Developing Dementia at Different Follow-Up Times (Risk Periods) According to Baseline Body Mass Index (BMI) after adjusting for sex, age, education, baseline Mini-Mental State Examination score, depressive symptoms, chronic disease up to baseline, and impairment in activities of daily living Obesity as a continuous variable: HR 0.96 (0.92–1.01) (incident dementia between years 3 and 9 of follow up) HR 0.98 (0.94–1.00) (incident dementia between years 1 and 9 of follow up) HR 0.97 (0.91–1.04) (incident dementia between years 6 and 9 of follow up) Categorical, n (%) HR (95% CI) for dementia between years 3 and 9 of follow up In BMI < 20.0 (underweight) 26 (30.9) 0.91 (0.59–1.40) In BMI 20.0–24.9 (normal weight) 115 (31.7) 1 (reference) And in BMI ≥25.0 (overweight/obese) 55 (23.6) 0.72 (0.52–1.02 | Comments: The participants of this study are older than some of the other studies in the geriatric populations with a mean age of 80.8. Though analysis for AD alone was done, unsure as to what proportion of dementia was specifically due to AD. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: Can’t Tell 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: No 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Ball, Berch, Helmers, et al., 2002 ACTIVE Trial | Geographical location: 6 metropolitan areas USA Setting: Community, Clinical – hospital and clinics, Other – senior housing Study design: RCT Test intervention: 3 different groups: -Training memory -Reasoning training -Speed processing training A subgroup of each had a booster at 11 months Comparator intervention(s): No contact group Number of participants enrolled: 2832, of this 2802 analyzed (30 excluded due to inappropriate randomization). Duration of follow up: 2 years Time from risk factor assessment to final cognitive assessment: 2 annual post test (2 years) | Age: Mean (SD): 73.6 (5.9) Range: 65–94 Sex: [n (%)] Female: 2127 (75.9%) Male: 675 (24.1%) Race/ethnicity: [n (%)] White: 2054 (73.3%) AA: 729 (26.0%) Other: 19 (0.7%) Baseline cognitive status: Non-demented MMSE above 22. Mean MMSE 27.3 (SD 2.0) (range 23–30) Inclusion criteria: Independent living Older than 65 Able to perform ADLs independently At risk for cognitve decline but without it yet. Exclusion criteria: -Younger 65y -MMSE lower 22 -Self report AD dx. -Substantial functional decline -Medical condition that could predispose to severe functional decline or death. - Severe loss of vision (20/70), hearing or communication abilities. - Prior participation in cognitive trials (recent cognitive training). Planning to move out of the area | Covariates/potential confounders adjusted for in analyses: Age, Sex, Educational level, Baseline cognitive status (they state this was done with overall pattern of results being similar but data not shown) Method(s) of assessing cognitive status: Other – specific to each of the interventions (see bove for each intervention measurement). Measures completed at: baseline, Immediate post test, first annual and second annual Memory composite: Hopkins verbal learning test, auditory verbal learning verbal test, Rivermead Behavioral Memory test. Reasoning composite: Word series, Letter series, letter sets. Speed of processing Useful field of view tasks 2–4.. Informant interview?: No | 1) Follow-up rate: 2802 included in analysis. (at 2 year follow up a total of 2244 assessed (80%), drop outs due to death, protocol violations, withdrawal due to scheduling, illness or lack of interest in continuing). 2) Important baseline differences: Randomized group was Slightly younger(mean 74 vs 75), more educated (13.5 vs 12.3 years), higher MMSE scores (27.3 vs 26.8) and fewer non white (27 vs 40%). This is in comparison with non randomized group (refused participation) there is no actual description of baseline characteristics or differences among intervention groups vs. control! 3) Outcome of interest #1 Every day problem solving at 2 years: Effect size compared to control: Memory training (−0.073), Reasoning training (−0.027), Speed training (0.031); p=ns for all Proportion showing improvement at 2 years (>1 SEM above baseline): Memory training (21%), Reasoning training (25%), Speed training (26%), control (23%) 4) Outcome of interest #2 ADL and IADL functioning. Proportion showing improvement at 2 years (>1 SEM above baseline): Memory training (17%), Reasoning training (16%), Speed training (17%), control (17%) 5) Outcome of interest #3 Everyday speed post test Proportion showing improvement at 2 years (>1 SEM above baseline): Memory training (33%), Reasoning training (29%), Speed training (30%), control (29%) 6) Outcome of interest #4 Driving habits Proportion showing improvement at 2 years (>1 SEM above baseline): Memory training (16%), Reasoning training (16%), Speed training (16%), control (18%) For the 4 primary outcomes assessed in each of the intervention groups, the effects were generally small (most below 0.10) and did not differe significantly in both assessments at 1 year or 2 years after intervention. Therefore no training effects on everyday function where detected at 2 years. Measurement of proximal outcome composites was performed (this is not their primary outcomes) Here they measured memory, reasoning and speed as outlined in previous column. Each intervention improved the targeted cognitive ability compared with baseline, durable to 2 years (p <.001 for all). Booster sessions enhanced training gains significantly in reasoning and speed (p.001) but not for memory. | Comments: Question 5 60% of the participants in each group where given boosters at 11 months and this data was analyzed separately. For RCTs: 1) Baseline comparability?: Can’t Tell 2) Valid AD/cognitive outcomes assessment?: Yes 3) Subjects/providers blind?: No 4) Outcome assessors blind?: Yes 5) Incomplete data adequately addressed?: Yes Differential dropout rate < 10%?:Yes 6) Differential dropout rate < 10%? Yes 7) Overall dropout rate < 30%?: Yes 8) Conflict of interest reported and insignificant?: No, first author has part ownership of company that makes the proximate test for speed of processing. 9) Randomization adequate?: Yes 10) Allocation concealment adequate?: Can’t Tell
Barnes, Alexopoulos, Lopez, et al. 2006 Cardiovascular Health Study | Geographical location: 4 US counties (NC, MD, CA, PA) Setting: Community Study designed: Prospectively Number of participants enrolled: 5888 in overall cohort; 2220 in this analysis Duration of follow up: 6 years Time from risk factor assessment to final cognitive assessment: 6 years from initial assessment. | Age: Mean: 74 Range: 64–92 Sex: [n (%)] Female: 1310 (59%) Male: 910 (41%) Race/ethnicity: [n (%)] African-Amer 200 (9%) Other (predom White) 2020 (91%) Baseline cognitive status: Non-demented (3ms>9=0) Inclusion criteria: Medicare eligible Live in 4 selected U.S communities Age >=65 Able to respond to questions MRI and 3MS completed Exclusion criteria: Institutionalized Cancer treatment Wheelchair bound No baseline lipid or statin use data Dementia 3MS < 90 at baseline | Risk factor 1 Current Depression CEDS 10-item (0–30) >=8 at baseline Method of assessing risk factor 1: [ Self-report Risk factor 2 Antidepressant medication use at baseline Method of assessing risk factor 2: Direct measurement-medication bottles Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Baseline cognitive status Vascular disease Method(s) of assessing cognitive status: Other –Clinical and neuropsych testing. MCI = “poor cognitive function that reflected a decline from prior level” but w/o dementia Informant interview?: No | 1) Follow-up rate: CT 2) Important baseline differences: Depressed subjects were more likely to be female and had higher clinical and subclinical vascular disease 3) Out come of interest #1 MCI Incidence (296 cases) CESD 0–2: Reference CESD 3–7: OR 1.37 (95% CI 1.00 to 1.88) CESD >=8: OR 2.09 (1.46 to 2.97) Stratified analysis by gender, age <=75, race, baseline 3MS, education <12, APOE e4 and antidepressant use did not show significant differences in the odds ratios 4) Outcome of interest #2 Continuous outcome [see instructions above] | Comment: High cognitive function at baseline (3MS >=90) Quality assessment: For observational studies: 1) Unbiased selection of the cohort)?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Can’t Tell 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Barnes, Cauley, Lui, et al., 2007 Study of Osteoporotic Fractures (SOF) Study | Geographical location: Baltimore, MD Minneapolis, MN Portland, OR Monongahela Valley, PA Setting: Community Study design: Prospective cohort Number of participants enrolled: 9704 Duration of follow up: Median 10 yrs (range 6–15) Time from risk factor assessment to final cognitive assessment: Median 10 yrs (range 6–15) | Age: Mean (SD): 71.7 (5.3) Range: 65–99 Sex: [n (%)] Female: 9704 (100%) Male: 0 (0%) Race/ethnicity: [n (%)] “primarily white” (>99%) Baseline cognitive status: Non-demented *May have included some demented, but unlikely to be many as 1^st^ follow-up assessment was 6 yrs after baseline Inclusion criteria: ≥ 65 yo; participating in the Study of Osteoporotic Fractures Study; Exclusion criteria: NR | Risk factor/exposure 1: smoking Method of assessing risk factor/exposure 1: Self-report Risk factor/exposure 2: depression and social networking Method of assessing risk factor/exposure 2: gds at year 2 Lubben Social Network Scale at year 2 Covariates/potential confounders adjusted for in analyses: Age Educational level Baseline cognitive status Study site Method(s) of assessing cognitive status: Other – Cognitive decline in a modified version of the MMSE (26 pts). Grouped as maintain cognition, minor decline, major decline Informant interview?: No | 1) Follow-up rate: over 15 yrs attrition due to causes other than death 832/9704 (9%) Attrition due to death was 4040/9704 (42%) 2) Important baseline differences: 3 outcome groups differed on almost all baseline characteristics: age, educ, baseline cog score, stroke, DM, HTN, distance walked daily, smoking, ETOH, physical performance, IADL, vision, self-rated health, depressive sxs, social network 3) Outcome of interest #1 Lack of smoking increased likelihood of maintaining cognition 4) Outcome of interest #2 Lack of DM increased likelihood of maintaining cognition 5) Outcome of interest #3 Lack of poor social network increased likelihood of maintaining cognition | Comments: 26 pt mmse, 3 groups: no decline in mmse, lowest 33%, use of middle group as a reference Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: Can’t Tell 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Partial 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Barnes, Mendes de Leon, Wilson, et al., 2004 Chicago Health and Aging Project | Geographical location: Chicago USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 6158 Duration of follow up: mean of 5.3 years Time from risk factor assessment to final cognitive assessment: 3–6 years | Age: Mean (SD): 73.94 (6.46) Sex: [n (%)] Female: 3827 (62.2%) Male: 2331 (37.8%) Race/ethnicity: [n (%)] African American: 3824 (62.1%) White: 2334 (37.9%) Baseline cognitive status: Normal Non-demented MCI CIND AAMI AACD (they did not exclude cognitively impaired at baseline) Inclusion criteria: Participant in Chicago Health and Aging Project; ≥ 65 yo; completed ≥ 1 follow-up Exclusion criteria: NR | Risk factor/exposure 1: Social network Method of assessing risk factor/exposure 1: Self-report Risk factor/exposure 2: Social engagement Method of assessing risk factor/exposure 2: Self-report (range 0–8) Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Marital status and income Method(s) of assessing cognitive status: A composite of the MMSE, Immediate and delayed recall of East Boston Story, and Symbol Digit Modalities Test using the average of z scores Informant interview?: No | 1) Follow-up rate: Baseline cohort: 6,102 1,241 died before the first follow-up interview 473 persons were lost to follow-up Of the remaining 4,388 people, 3,899 (88.9%) completed at least one follow-up interview; 3,899 or 6,102 original cohort (63.9%) 2) Important baseline differences: NR 3) Outcome of interest #1 After controlling for education, marital status, and income, for each social network there was a 0.002 unit (SE 0.001) reduction in rate of cognitive decline p = 0.001 4) Outcome of interest #2 Frequency of social engagement was strongly related to rate of cognitive decline, with a reduction of 0.009 unit (SE 0.001) for each point on the social engagement scale. 5) Outcome of interest #3 Results were not affected after the analyses was done after dropping the participants lowest 10 percentile of cognition. | Comments: This article did not exclude patients who had cognitive impairment at baseline. In another paper on the same populations, a third of the sample had MMSEs less than 24 at baseline. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: Can’t Tell 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Can’t Tell. They did use more than one cognitive test. 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: No 10) Analysis controls for confounding?: Partial. Did not control for baseline cognitive status. 11) Analytic methods appropriate?: Yes.
Bernick, Katz, Smith, et al., 2005 Cardiovascular Health Study (CHS) | Geographical location: 4 US Counties (NC, MD, CA, & PA) Setting: Community Study design: Prospective cohort Number of participants enrolled: 5880 in overall cohort 3334 for this analysis Duration of follow up: Mean of 5.1 years Time from risk factor assessment to final cognitive assessment: Mean of 5.1 years from initial assessment | Age: Mean (SD): 72.9 (3.6) to 75.9 (5.8) Sex: Female: 2014 (60.4%) Male: 1320 (39.6%) Race/ethnicity: Non-black 2776 (83.3%) Black 558 (16.7%) Baseline cognitive status: Non-demented (3MS>80) Inclusion criteria: Medicare eligible; live in 4 selected US communities; ≥ 65 yo; able to respond to questions; underwent study MRI Exclusion criteria: Institutionalized; CA Tx; wheelchair-bound; no baseline lipid or statin use data; 3MS score ≤ 80 or no baseline; < 2 yrs cognitive testing; incident TIA or stroke | Risk factor/exposure 1: No statin; Intermittent statin (2–4 yrs continuous Tx or 3–5 yrs nonconsecutive use); Continuous statin (>4 yrs continuous Tx) Method of assessing risk factor/exposure 1: Direct measurement – medicine bottles Risk factor/exposure 2: Age, sex, educational level (self-report), cholesterol, APOE e4 (direct measurement) Method of assessing risk factor/exposure 2: Self-report Direct measurement Covariates/potential confounders adjusted for in analyses: age, gender, race APOE e4, cholesterol Method(s) of assessing cognitive status: Other – 3MS Informant interview?: No | 1) Follow-up rate: Uncertain Continuous outcome [ 3MS Baseline values, mean (SD) Continuous (n=293): 93.7 (4.5) Intermittent (n=158): 92.9 (4.6) No treatment (n=2,031): 92.9 (4.9) No treatment (diet recommended, n=501): 92.9 (5.1) No treatment (drug recommended, n=351): 93.1 (4.9) 3MS Unadjusted mean change per year* Continuous (n=293): −0.26 (−0.56 to 0.05) Intermittent (n=158): −0.50 (−0.92 to − 0.09) No treatment (n=2,031): −0.75 (−0.86 to −0.63) No treatment (diet recommended, n=501): −0.61 (−0.85 to −0.38) No treatment (drug recommended, n=351): −0.73 (−1.01 to −0.45) 3MS adjusted mean change per year (age, gender, race APOE e4, cholesterol) Continuous (n=293): −0.27 (−0.61 to 0.06) Intermittent (n=158): −0.45 (−0.89 to − 0.01) No treatment (n=2,031): −0.76 (−0.89 to −0.63) No treatment (diet recommended, n=501): −0.61 (−0.87 to −0.36) No treatment (drug recommended, n=351): −0.70 (−1.02 to −0.38) * not specified but should represent f/u – baseline since it is described as a decline | Comments: Many excluded due to missing data; did not control for vascular risk factors – but did exclude those with incident TIA/Stroke; N was difficult to assess because had 5880 in overall cohort, then excluded many (legitimately) but other exclusions could have introduced bias (e.g. < 2 yrs f/u cognitive testing, missing lipid data). Time from risk factor assessment also difficult. Initial assessment probably 10 yrs, but assessed repeatedly. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Can’t Tell 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Berr, Balansard, Arnaud, et al., 2000 EVA Study | Geographical location: Nantes district, France Setting: Community Study design: Prospective cohort Number of participants enrolled: 1389 Duration of follow up: 4 yr Time from risk factor assessment to final cognitive assessment: 4 yr | Age: Mean 65.0 (3.0): Sex: Female: 684 (58.7) Male: 482 (41.3) Race/ethnicity: NR Baseline cognitive status: Non-demented (this is assumed based on the age of the sample. Demented not overtly excluded, but assume few demented at baseline) Inclusion criteria: Born between 1922– 1932 Living in Nantes district of France Enrolled from electoral rolls and, to a lesser extent, ad campaigns. When ind enrolled automatically asked spouse to participate. Exclusion criteria: None | Risk factor/exposure 1: Selenium Method of assessing risk factor/exposure 1: Direct measurement Risk factor/exposure 2: carotenoids Method of assessing risk factor/exposure 2: Direct measurement Risk factor/exposure 3: RBC vit E Method of assessing risk factor/exposure 3: Direct measurement Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Baseline cognitive status Depressive sxs ETOH and tobacco use BMI Cholesterol triglycerides Method(s) of assessing cognitive status: Other – cog decline defined as loss of 3 pts on MMSE – represented worse 15^th^ %tile change Informant interview?: No | 1) Follow-up rate: 1166/1389 2) Important baseline differences: Compared based on TBAR level (not sure how to apply to other risk factors) TBAR > 75^th^%tile had greater ETOH use, fewer never smoked individuals, higher cholesterol, lower RBC vit E, higher TBAR level 3) Outcome of interest #1 Selenium -<25^th^ %tile vs ≥25%tile OR=1.58 (1.08–2.31) for cog decline 4) Outcome of interest #2 Plasma carotenoids -<25^th^ %tile vs ≥25%tile OR=1.17 (0.75–1.81) for cog decline 5) Outcome of interest #3 RBC Vit E -<25^th^ %tile vs ≥25%tile OR=1.04 (0.68–1.56) for cog decline | Comments: Question: Q2 Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Partial 2) Selection minimizes baseline differences in prognostic factors?: Partial 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Beydoun, Kaufman, Satia, et al., 2007 ARIC | Geographical location: Four US communities (NC, MS, MN, & MD) Setting: Community Study design: Prospective cohort Number of participants enrolled: 7814 2251 with all data used in this analyses Duration of follow up: 9 yrs overall 6 yrs for two cognitive assessments used Time from risk factor assessment to final cognitive assessment: 9 yrs from blood draw to final cognitive assessment used in analyses cognitive decline was measured over 6 yrs | Age: Mean (SD): No decline: 56.2 (4.2) Decliners:57.7(4.2) Sex: [n (%)] Female: 50.7% Male: 49.3% Race/ethnicity: [n (%)] White 100% Baseline cognitive status: Those with impairment are not intentionally excluded – but given the age range of the sample at baseline, suspect most met criteria for normal cognition Inclusion criteria: a) complete plasma fatty acid data, b) survived to visit 4, c) complete cognitive data visits 2 and 4, e) age 50 or older at baseline Exclusion criteria: opposite of the inclusion criteria | Risk factor/exposure 1: n-3 fatty acids; mean values compared and OR for 1 SD difference. Method of assessing risk factor/exposure 1: Direct measurement Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Smoking, ETOH, caffeine use Physical activity index BMI Dietary factors Baseline cognitive status (essentially did this but in somewhat more elaborate manner) Considered as effect modifiers: APOE Comorbid med cond Method(s) of assessing cognitive status: Other – Cognitive decline using Reliable change index for 3 tests: COWA, DSST, and delayed word recall test Informant interview?: No | 1) Follow-up rate: 2251 with all data available out of 7814 enrolled overall 2) Important baseline differences: Reported differences between decliners and non-decliners at baseline: Non-decliners were younger, more physically active, less depressive sxs, relatively hypocoagulable profile. Decliners had higher baseline cognitive score 3) Outcome of interest #1- Numerous results given for comparisons (selected ones given here) a) Total PUFA- no decliners higher mean values than decliners (OR=0.55; 0.37–0.81) b)palmitic acid-no decliners lower than decliners (OR=1.28; 1.07,1.54) c) greater DHA (OR=.0.74; 0.57– 0.97) and EPA (OR=0.73; 0.58–0.93) associated with less decline on verbal fluency | Comments: There are many comparisons done in this paper with only a few significant results and p-value set at 0.05. Question: Q2 Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: Can’t Tell 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Partial
Beydoun, Kaufman, Sloane, et al., 2008 Atherosclerosis Risk in Communities (ARIC) | Geographical location: Four US communities (NC, MS, MN, & MD) Setting: Community Study design: Prospective cohort Number of participants enrolled: 7814 Duration of follow up: 9 yrs Time from risk factor assessment to final cognitive assessment: 9 yrs but need to look at how replicate FFQ info used – cognitive decline was measured over 6 yrs | Age: Mean (SD): 56.6 (4.31) Median: Range: 50–65 Sex: [n (%)] Female: 54.6% Male: 45.4% Race/ethnicity: [n (%)] White 81.5% Baseline cognitive status: Those with impairment are not intentionally excluded – but given the age range of the sample at baseline, suspect most met criteria for normal cognition Inclusion criteria: a) complete dietary intake data at visit 1, b) survived to visit 4, c) complete cognitive data visits 2 and 4, e) age 50 or older at baseline Exclusion criteria: opposite of the inclusion criteria | Risk factor/exposure 1: Dietary Assessment Method of assessing risk factor/exposure 1: Self-report Food Frequency questionnaire Risk factor/exposure 2: Blood assay of dietary data Method of assessing risk factor/exposure 2: Self-report Direct measurement of blood pressure for all subjects and blood samples for subset at visit 1(n=2251) Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Baseline cognitive status (essentially did this but in somewhat more elaborate manner) APOE Behavioral factors Nutritional factors Hypertension Method(s) of assessing cognitive status: Other – Cognitive decline using Reliable change index for 3 tests: COWA, DSST, and delayed word recall test Informant interview?: No | 1) Follow-up rate: for self-report dietary data – 7814. For blood assay of dietary data – 2251. Only those who had all data were included in analyses. 2) Important baseline differences: N/A 3) Outcome of interest #1- a) adjusted analyses b) decline in word list recall modestly reduced with increase in long-chain n-3 fatty acid intake (3H) as % of total energy intake c) decline in verbal fluency reduced by increase in long-chain and all n-3 fatty acids (3H and 3) as % of total energy intake, by ratio 3H/6H and by 3Hin g day^−1^ 4) Outcome of interest #2 interaction with HTN a) finding 3b above maintained in HTN subgroup b) for DSST, interaction for ratio 3H/6H with HTN - showed less decline for HTN compared to non- HTN c) finding 3c above stronger in HTN with a sig interaction for 3H in gday ^−1^ 5) Outcome of interest #3 Subgroup with plasma – a) generally less decline with higher concentration of n-3 fatty acid in their plasma cholesteryl esters and phospholipids and elevated ratio of n-3/n-6 fatty acids– but generally not significant except for verbal fluency b) for verbal fluency, HTN group showed less decline for 3H and 3H/6H for plasma cholesteryl esters and 3H/6H for plasma phospholipids | Comments: No results given for calibrated food frequency measures Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: Can’t Tell 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Partial for food frequency, Yes for blood assays 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes – just included those with complete data – selective attrition may have some influence 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Can’t Tell
Bierman, Comijs, Rijmen, et al., 2008 LASA Study | Geographical location: The Netherlands Setting: Community Study design: Prospective cohort Number of participants enrolled: 2351 Duration of follow up: Up to 9 years Time from risk factor assessment to final cognitive assessment: Up to 9 years | Age: at baseline Mean (SD): 69.5 (8.6) Sex: [n (%)] Female: 1097 (46.7%) Male: 1254 (53.3%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Not specified MMSE = 27.31 (2.4) Inclusion criteria: Random sample of 55–85 y.o. from 11 municipalities in the Netherlands Analyses restricted to those age 62 and older with snxiety and cognition measured at baseline Exclusion criteria: NR | Risk factor/exposure 1: Anxiety at 4 time points Method of assessing risk factor/exposure 1: Self-report; Hospital Anxiety and Depression Scale – Anxiety subscale: 0– 7=normal; 8–10 =mild anxiety, >10 = moderate/severe anxiety Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Chronic disease count Depressive symptoms Alcohol consumption Benzodiazapine use Method(s) of assessing cognitive status: Other – measured at 4 timepoints: General cognitive functioning: MMSE (0– 30) Fluid intelligence: Ravens coloured progressive matrices (0–24) Processing speed: adjusted version of coding task (2–53) Episodic memory auditory verbal learning test: 3 learning trials (0–45); delayed recall (0–15) Informant interview?: No | 1) Follow-up rate: 1469/2351 (62.5%) at year 9 Drop-out was associated with age, gender, education, more anxiety symptoms and lower cognitive performance 2) Important baseline differences: NR 3) Outcome of interest #1 No significant association between anxiety symptoms and cognitive decline for any of the cognitive tests (parameter estimates not reported) | Comments: Subsample of LASA study; 62.3% of those invited responded; older adults and females in more urban areas were less likely to respond Analysis not limited to those with normal cognition at baseline Used random regression models Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Partial 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: No 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Blair, Folsom, Knopman, et al., 2005 ARIC | Geographical location: Medicare files Forsyth County, NC; Jackson, MS; suburban Minneapolis, MN; Washington County, MD Setting: Probability sample Community Study design: Prospective cohort Number of participants enrolled: 1693 African- Americans and 6202 Caucasians used in analysis Duration of follow up: 6 years Time from risk factor assessment to final cognitive assessment: 6 years | Age: Mean (SD): 55 SD varied by APOE genotype Sex: [n (%)] Female: not specifically stated, but APOE genotype, but approximately 60% female in AA population; 49% women in Caucasians Male: AA ~40% White ~51% Race/ethnicity: [n (%)] 78.6 % white 21.4 % black Baseline cognitive status: Non-demented Inclusion criteria: Men and women age 45 to 64 at enrollment. AAs sampled exclusively in Jackson and over-sampled in Forsyth County. Exclusion criteria: Missing cognitive data; did not have apoe genotyping, incident or prevalent stroke, taking antidepressants, anxiolytics, sedatives, anticonvulsants, narcotics, antipsychotics, or chemotherapy. | Risk factor/exposure 1: APOE ɛ4 Method of assessing risk factor/exposure 1: Direct measurement Genotyping Covariates/potential confounders adjusted for in analyses: Age, sex, education, baseline cognitive scores, cigarette smoking, use of NSAIDs, diabetes, hypertension, hypercholesteremia Method(s) of assessing cognitive status: Delayed word recall (DWR); Digit Symbol Substitution (DSS); Word Fluency (aka controlled oral word association test) Informant Interview No | 1) Follow-up rate: 7895/15,792= 50% 2) Important baseline differences: Higher cholesterol, LDL and lower HDL in E4 groups; in AAs E4 carriers had increased carotid intima-media thickness; Caucasians homozygous for E4 more likely to have diabetes and less likely to be hypertensive. DSS was only cognitive test different among APOE genotypes- lowest in E4/4 caucasians even after adjustment for age, sex and education. Not significant in AAs after adjustment. 3) Outcome of interest #1 AA: (adjusted for age, sex, education, education, baseline score, hypertension, DM) only the DSS showed a dose-response relation between APOE genotype and performance. E4/4 declined by 3.99 symbols, E3/3 declined by 0.98; and E2 group (E2/2 and E2/3) declined by 0.43 symbols (p=0.002) Risk for decline in AA E4/4 compared to E3/3 DWR OR = 1.72 (95% CI 0.97–3.06) DSS OR= 1.86 (1.06–3.27) Caucasians: (adjusted for age, sex, education, education, baseline score, hypertension, DM) the DWR and DSS showed a dose-response relation between APOE genotype and performance. DSS test: E4/4 declined by 4.54; E4/2 or E4/3 group declined by 3.20 symbols, E3/3 declined by 2.69; and E2 group (E2/2 and E2/3) declined by 2.51 symbols. (p<.0001) DWR scores: E4/4 declined by .31; words; E4/2 or E4/3 group declined by .21 words, E3/3 declined by .13 words; and E2 group (E2/2 and E2/3) declined by .06 words. (p=.02) Risk for decline in Cauc. Compared to E3/3 genotype E2 group DWR OR = .78 (95% CI .61–.98); E4 group (E3/4 or E2/4) DWR OR 1.19 (1.01–1.41) and E4/4 OR DWR 1.53 (0.95–2.45) DSS OR E4/4 compared to E3/3 = 2.02 (1.31–3.12) Word fluency was not related to APOE genotype in AA or caucasians. 4) Outcome of interest #2 Interaction between APOE genotype and other risk factors. Interaction between APOE and hypercholesterolemia (p value for interaction = 0.008) Interaction between APOE genotype and diabetes mellitus (p value for interaction = 0.04) | Comments: High dropout rate. Baseline cognitive status was not defined. Excluded people on many medications potentially biasing study. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Partial 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Partial 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Partial 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Blasko, Jellinger, Kemmler, et al., 2008 VITA | Geographical location: Vienna, Austria Setting: Community Study design: Prospective cohort Number of participants enrolled: 606 Duration of follow up: 30 months Time from risk factor assessment to final cognitive assessment: Change in homocysteine, so 0–30 months | Age: Mean (SD): 75.8 (0.5) Sex: [n (%)] Female: 359 (59.4%) Male: 247 (40.6%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Age ≥75 Complete baseline data Exclusion criteria: Dementia Schizophrenia | Risk factor/exposure 1: homocysteine ; analyzed as log transformed values Method of assessing risk factor/exposure 1: Direct measurement plasma stored frozen doesn’t say for how long, doesn’t say if fasting or not. Covariates/potential confounders adjusted for in analyses: Age, Sex, Educational level, at least one apoE4 Method(s) of assessing cognitive status: NINCDS-ADRDA DSM MCI diagnosed if one of CERAD neuropsychatric test ≥ 1.5 SD below the mean Informant interview?: No | 1) Follow-up rate: 83.2% of the 119 lost to follow up, 38 died, 1 was dxd schizophrenic, 10 had only telephone interviews and 70 refused. 2) Important baseline differences: Not clearly stated. . No information on the low vs high homocysteine at baseline groups. 3) Outcome of interest #1: The change in homocysteine over 2.5 years for those who converted to AD: OR for AD in those with doubling of homocysteine 4.2 (1.6–11.0) 4) Outcome of interest #2: For persons who deteriorated to mci OR AD, OR for AD in those with doubling of homocysteine 2.2 (1.2– 4.1), for just conversion to mci alone, table notes “no association” but data not given. | Comments: Question 1 Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Partial. Don’t see information on baseline differences. 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Can’t Tell 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Borenstein, Wu, Mortimer, et al., 2005 Kame project (whose participants were followed in the Ni-Hon- Sea Project) | Geographical location: King County, WA Setting: Community Study design: Prospective cohort Number of participants enrolled: Initial cohort of 3045 eligible participants; 1985 baseline screened; 1859 enrolled. Duration of follow up: Cognition was assessed at baseline and at each of four follow up waves. Subjects with a score of >87/100 were followed every 2 yrs. Those with scores of 87 or less at any biennial follow up were then evaluated with a full evaluation. Total follow up: 6 yrs Time from risk factor assessment to final cognitive assessment: 6 yrs(SD =2.7) | Cases (n=90) Age: Mean (SD): 78 yrs Sex: Female: 61 (68%) Male: 29 (32%) Non Cases (n=1769) Age: Mean (SD): 72 yrs Sex: Female: 978 (55%) Male: 791 (45%) Race/ethnicity: Predominantly Japanese American Baseline cognitive status: Non-demented Inclusion criteria: 65 yrs and older; free of AD at baseline Exclusion criteria: NR | Risk factor/exposure 1: Diabetes mellitus Method of assessing risk factor/exposure 1: Self-report Risk factor/exposure 2: Is the presence of Apolipoprotein E- (ApoE) a risk factor for AD? Method of assessing risk factor/exposure 2 Direct measurement Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Baseline cognitive status Developmental risk factors Vascular risk factors Method(s) of assessing cognitive status: NINCDS-ADRDA DSM-IV Other – Cognitive Abilities Screening Instrument(CASI) Informant interview?: No | 1) Follow-up rate: Obtained ApoE genotyping on 1111/1859(59%) 2) Important baseline differences: NA 3) Outcome of interest #1 Cox proportional hazard models for vascular risk factors, by positive ApoE status demonstrated a HR 0.51 with a 95% CI 0.12–2.26. 4) Outcome of interest #2 The risk for AD was stronger for women who carried ApoE 4 allele than for men. Women who carried an ApoE 4 allele was also higher (HR=2.37,95% CI 0.93–6.01, p=0.07) than for those who did not (HR=0.98, 95% CI 0.47–2.04) Women who were negative for ApoE 4 allele: HR 0.98, 95% CI 0.47–2.04, p=0.95. | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Partial; genotyping obtained on 59% 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Bosma, van Boxtel, Ponds, et al., 2002 Maastricht Aging Study” (MAAS) | Geographical location: The South of the Netherlands Setting: Clinical –Family practice clinics. Study design: Prospective cohort Number of participants enrolled: 1823 enrolled of whom, 1069 met inclusion criteria. Duration of follow up: 3 years. Time from risk factor assessment to final cognitive assessment: 3 years | Age: Range: > 50 (49 – 81 at baseline) Since they stratified the sample, it is hard to get a specific age number. Sex: Both genders included; no specific numbers reported Race/ethnicity: NR Baseline cognitive status: Non-demented Inclusion criteria: ≥50 yrs Exclusion criteria: Chronic neurological pathology Mental retardation Chronic psychotropic drug use Dementia | Risk factor/exposure 1: Physically active sports Method of assessing risk factor/exposure 1: Self-report Risk factor/exposure 2: mentally active sports (e.g., chess, puzzles) Method of assessing risk factor/exposure 2: Self-report Risk factor #3: organizational memberships (e.g., clubs) Method of assessing risk factor/exposure 3: Self report. Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Baseline cognitive status Length of follow up interval. Method(s) of assessing cognitive status: Other – Stroop Color – Word Test (interference sub-task), the Verbal Learning Test (immediate and delayed recall sub- tasks), the Letter Digit Coding Test, the Word Fluency Test, and the Mini-Mental State Examination Method of assessing dementia: NR Informant interview? No | 1) Follow-up rate: 1069 participants recruited. 138 refused. 50 died during follow up period and 8 developed dementia. Therefore, only 830 (77.64%) persons were used in the analysis. 2) Important baseline differences: NR 3) Outcome of interest #1: Physical activities were significantly associated with the letter digit coding. β = 0.82 p <0.05 4) Outcome of interest #2 Mental activities were significantly associated with Letter digit coding β = 0.1.18 p <0.01 and MMSE β = 0.40 p <0.01. 5) Outcome of interest #3 Social activities were significantly associated with total recall β = 0.94 p <0.05 and Delayed recall β = 0.30, p <0.05 6) Outcome of interest #4 Number of activities treated as a continuous variable was associated with Letter digit coding β = 0.66, p <0.01, Word fluency β = 0.34, p <0.05, Delayed recall β = 0.16, p <0.05 and MMSE β = 0.17, p <0.01 | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Partial, selection methods missing some detail 2) Selection minimizes baseline differences in prognostic factors?: Yes. 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: No 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: No 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Breitner, Haneuse, Walker, et al., 2009 Adult Changes in Thought (ACT) | Geographical location: Seattle, WA Setting: Community Study design: Prospective cohort Number of participants enrolled: 3392 (1994–2003) 2581 from 1994–6 811 from 2001–3 Duration of follow up: Up to 12 years Original cohort=10–12 Expansion cohort=3–5 Time from risk factor assessment to final cognitive assessment: between 3 and 12 years | Age: Median: 74.8 Range: ≥ 65 y Sex: [n (%)] Female: 1636 (59.8) Male: 1100 (40.2) Race/ethnicity: [n (%)] White : 2473 (90.4) Other: 263 (9.6) Baseline cognitive status: Non-demented Inclusion criteria: ≥ 65 yo Membership in group health plan of ≥ 10 y At least one follow-up visit Exclusion criteria: Presence of dementia or AD | Risk factor/exposure 1: NSAIDs prescribed and/or used over time Method of assessing risk factor/exposure 1: NSAID use Self-report Medical record classified as heavy use (≥ 500 Standard daily doses within 2 years); moderate 60–499 SDD; light <60 SDD Covariates/potential confounders adjusted for in analyses: (Analysis was stratified by age) Race Sex Educational level Comorbidities plausibly assoc’d with NSAIDs or dementia APOE status Method(s) of assessing cognitive status: 2-stage evaluation with CASI, then diagnostic evaluation for CASI ≤ 85; NINCDS-ADRDA DSM-IV Informant interview?: No | 1) Follow-up rate: For primary analysis: At least one F/U visit= 90% By end of study, 10% withdrew and 24% had died For secondary analysis: Two or more F/U visits = 69% 2) Important baseline differences: None with standard demographics Degree of NSAID exposure - decreased with (no surprises) Exercise, smoking, normal wt - increased with (no surprises) Limitation in AODL, obesity, total prescriptions, use of H2 blockers or proton pump inhibitors, Dx of osteoarthritis At baseline, 50% were non or light users of NSAIDs, 37% were moderate users, and 13% were heavy users 3) Outcome of interest #1 All-cause Dementia using pharmacy data 476 (17%) In all 3 models, no reduction in risk of dementia among NSAID users; in fact, risk appears to increase c use M1 – low=1.00; mod= 1.13 (0.92– 1.38); heavy=1.51 (1.18–1.94) M2– low=1.00; mod= 1.09 (0.88– 1.35); heavy=1.48 (1.13–1.93) M3– low=1.00; mod= 1.13 (0.90– 1.43); heavy=1.66 (1.24–2.24) This result was robust in 2° analyses 4) Outcome of interest #2 Alzheimer’s Disease 356 of 476 (13%) attributed to AD Dementia using pharmacy data In all 3 models, no reduction in risk of dementia among NSAID users; in fact, risk appears to increase c use M1 – low=1.00; mod= 1.17 (0.92– 1.47); heavy=1.40 (1.05–1.87) M2– low=1.00; mod= 1.18 (0.92– 1.52); heavy=1.38 (1.01–1.89) M3– low=1.00; mod= 1.26 (0.97– 1.65); heavy=1.57 (1.10–2.23) This result was robust in 2° analyses | Comments: Results did not differ significantly when pharmacy + self report data used Cohort with health insurance Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: No explanation given why there was an expansion cohort, but was adjusted for in analysis 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes, Cox proportional hazards models stratified by age with time-dependent covariates. Did not include NSAID use in last year prior to Dx to avoid confounding from suspected interaction between NSAID and AD. Secondary analyses were done to explore interactions with age, test influence of H2 blockers and proton pump inhibitors, recency of exposure, specific NSAID mode of action, time- frame of enrollment and criteria used to dx AD
Bretsky, Guralnik, Launer, et al., 2003 MacArthur Successful Aging Study | Geographical location: Durham, NC, East Boston, MA, New Haven, CT Setting: Community Study design: Prospective cohort Number of participants enrolled: 965 Duration of follow up: 7 years Time from risk factor assessment to final cognitive assessment: Not stated when genotyping was performed | Age: Mean (SD): E4+ 73.8 (2.7) E4− 74.1 (3.0) Range: 73–79 Sex: [n (%)] Female: 539 (44%) Male: 426 (56%) Race/ethnicity: [n (%)] 725 (75%) white 234 (24.4%) black 6 (0.6%) other Baseline cognitive status: Participants who scored in the top third of the cognitive and physical screening tests for their age group Inclusion criteria: Age 70–79 in 3 communities. Aim is to identify those in the top 1/3 of population. No reported disability on 7 item ADL; no more than 1 reported mild disability on 8 items of tapping, gross mobility and ROM; ability to hold a semi-tandem balance for at least 10 seconds; ability to stand from a seated position five times in 20 seconds. Cognitive criteria include scoring 6 or more on SPMSQ; remembering 3 or more of 6 elements on a delayed recall of a short story Exclusion criteria: NR | Risk factor/exposure 1: Apolipoprotein E genotype Method of assessing risk factor/exposure 1: Direct measurement Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Method(s) of assessing cognitive status: Other – Short Portable Mental Status Questionnaire (SPMSQ); Abstraction (based on four items from similarities test of Wechsler adult intelligence scale- revised (0–16 points); delayed spatial recognition (0–17); language (Boston naming test; 0–18); spatial ability (0–20). Two summary scores were made from the subscores. Total cognition included sum of all subscores (0–89). Total memory score is composed of sum of delayed incidental and spatial recall (0–31). Decline on SPMSQ was defined as a score ≤6. A decline in other domain was defined as ≥1 SD decline from baseline score. Informant interview?: No | 1) Follow-up rate: 88.8% at 3 years and 67.1% at 7 years 2) Important baseline differences: Distribution of E4 carriers was different by ethnicity 3) Outcome of interest #1 Adjusted OR (95% CI) at year 3 in APOE e4 vs non-e4: Only Naming ( OR=2.7; CI = 1.2 –5.9) and Copying figures (OR =1.8; CI = 1.1–3.1) showed significant differences. Adjusted OR (95% CI) Odds of cognitive decline at year 7 In APOE e4 vs non-e4 SPMSQ 2.3 (1.5–3.4) Total cognition 2.0 (1.1–3.6) Memory 1.7 (1.1–2.5) Naming 2.5 (1.5–4.2) Figures 2.1 (1.4–3.3) Similarity 1.8 (1.1–3.1) Not significant difference Story recall 1.4 (0.9–2.1) Spatial recognition 1.3 (.9–2.0) | Comments: Participants were selected to be in top 1/3 of population, so applicability to general population is limited. Baseline cognitive status assessed by 9 question SPMSQ. To participate, subjects had to have score ≥6, which may not exclude mild dementia. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yyes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Carmelli, Swan, Reed, et al., 1998 National Heart Lung and Blood Institute Twin Study (WW II veterans sub-study) | Geographical location: USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 410 Duration of follow up: 10 years Time from risk factor assessment to final cognitive assessment: 10–25 years | Age: Mean 63.2 (2.9) Range: 73 and up Sex: [n (%)] Female: 0 (0%) Male: 410 (100%) Race/ethnicity: [n (%)] White: 410 (100%) Baseline cognitive status: did not eliminate cognitive impaired but mean age was 63.1 (2.9) and mean mmse 27 for overall group. Inclusion criteria: Participating in National Heart, Lung, and Blood Institute Twin Study Evaluated for cognitive function at third and fourth cardiovascular exam Exclusion criteria: See NHLBI Twin Study, Reference 16 | Risk factor/exposure 1: htn Method of assessing risk factor/exposure 1: mean bp >140/90 or use of antihypertensive medication at any of the exams on or prior to baseline cognitive assessment (10–25 years before f/u cognitive assessment) Risk factor/exposure 2: dm Method of assessing risk factor/exposure 2: 1 hour post prandial glc > 200 or use of hypoglycemic agent or insulin. Covariates/potential confounders adjusted for in analyses: Age, Race, Sex, baseline score, incident CVD Method(s) of assessing cognitive status: change in test scores Informant interview?: No | 1) Follow-up rate: 410/589, 69.6% 2) Important baseline differences: baseline difference are given for apoE4 present and absent and the only significant difference was more errors in Benton visual retention test for those without apoE4 3) Outcome of interest #1 hyperglycemics experienced a significantly greater decline on dss, bvrt and mmse. 4) Outcome of interest #2 hypertensives also experienced a greater decline on the dss but not mmse and bvrt. p values (non-exact) are given for one sided significance 5) Outcome of interest #3 Subjects with dm and htn had a greater decline on the dss than those with neither risk factor and more than expected for both combined (but not significant) Mean change (SD) APOEe4 + and Hyperglyc present MMSE 1.66 (.39) DSS 7.84 (1.08) BVRT 1.05 (.26) APOEe4+ and hyperglyc absent MMSE 0.73 (.28) DSS 4.47 (.76) BVRT .53 (.19) APOEe4 – and hyperglyc present MMSE .47 (.2) DSS 4.14 (.56) BVRT .84 (.14) APOEe4- and hyperglyc absent MMSE .47 (.16) DSS 3.34 (.45) BVRT .37 (.11) All scores are significantly different from 0 and statistically significant at p<.05 | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Partial, WWII veteran male twins 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Ppartial 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: No 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Cherbuin, Reglade- Meslin, Kumar, et al., 2009 | Geographical location: Canberra and Queanbeyan, Australia Setting: Community Study design: Prospective cohort Number of participants enrolled: 2082 (analytical sample) Duration of follow up: 4 yrs Time from risk factor assessment to final cognitive assessment: 4 yrs | Age: Mean (SD): Normal Wv 2: 62.5(1.5) Mild-impaired Wv2: 62.53(1.6) Sex: Female: 1020 (48.99%) Male: 1062 (51.01%) Race/ethnicity: [n (%)] White: 1910 (91.7%) Other: 172 (8.3%) Baseline cognitive status: Cognitively normal Inclusion criteria: At baseline, age 60–64 and cognitively normal Exclusion criteria: None except as covered by inclusion criteria | Risk factor/exposure Alcohol Smoking Anxiety medication Anxiety and depressive symptoms Method of assessing risk factor/exposure 1 Self-report for alcohol using the AUDIT interview Self report for smoking Unclear how medication use was obtained Anxiety and depressive symptoms – Goldberg anxiety/depression scales-threshold for significant symptoms not reported Blood pressure measured Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Method(s) of assessing cognitive status: DSM Other – published criteria for MCI, AAMI, AACD and other cognitive disorder Informant interview?: Yes (when available) | 1) Follow-up rate: 2082/2551 (81.7%) 2) Important baseline differences: Reported differences by outcome not by exposure 3) Outcome of interest #1 Incident MCI (18 incident cases): alcohol intake associated with lower risk of MCI (OR=0.59; 95% CI 0.37– 0.92; p=0.021) Quadratic model – U-shaped association showing higher risk for low and high drinking groups (OR=1.58; 1.18–2.11; p=0.002) Past smoking (OR 3.22; 1.05–9.87) Anxiety medication (OR 3.58; 0.97– 13.22) Goldberg depression scale (OR 1.54; 1.07–2.22) and anxiety scale (OR 0.83; 0.58–1.18), antidepressant medication (OR 2.79; 0.38–20.57), Diabetes (OR 0.53; 0.06–4.6), BMI (OR 1.01; 0.91–1.11) reported in full but not reduced model used for other results. 4) Outcome of interest #2 Incident any mild cognitive disorder(MCD, n=64): alcohol intake associated with lower risk (OR=0.75; 0.57–1.00; p=0.046) Diastolic Blood pressure (OR 0.96; 0.92–0.99) Past smoking (OR 1.97; 1.12–3.44) Antidepressant medication (OR 3.25; 1.51–7.00) Anxiety medication (OR 0.67; 0.2–2.28), Goldberg depression scale (OR 1.16; 0.96–1.4) and anxiety scale (OR 0.93;0.79–1.1), diabetes (OR 1.09; 0.48–2.44), BMI (OR 1.03; 0.98–1.07) reported in full but not reduced model used for other results. Quadratic model – U-shaped association showing higher risk for low and high drinking groups (OR=1.17; 0.98–1.40; p = 0.087) | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Partial, only some measures validated 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Partial, for MCI too many candidate independent variables for the number of incident cases
Christensen, Batterham, Mackinnon, et al., 2008 | Geographical location: Canberra and Queanbeyan Australia Setting: Community Study design: Prospective cohort Number of participants enrolled: 2551 Duration of follow up: 4 years Time from risk factor assessment to final cognitive assessment: 4 years | Age: Mean (SD): 60–64 Sex: [n (%)] Female: 1329 (51.72%) Male: 1232 (48.28%) (This is based on the first wave). Race/ethnicity: [n (%)] All Caucasian Baseline cognitive status: All Inclusion criteria: 60–64% Alive at the time of second survey Those who were not genotyped Exclusion criteria: NR | Risk factor/exposure 1: Genotype Method of assessing risk factor/exposure 1: Direct measurement Cheek swab Risk factor/exposure 2: Education Head Injury Premorbid intelligence Method of assessing risk factor/exposure 2: Self-report Direct Measurement Covariates/potential confounders adjusted for in analyses: Educational level Head Injury Premorbid intelligence Method(s) of assessing cognitive status: Other – change on word list memory task, MMSE, SDMT, Digit Span Backwards, Reaction time task Informant interview?: Yes | 1)Follow-up rate: 2551 in the first wave and 2222 in the second wave. Of the 770 234 refused or were unable to be interviewed due to medical reasons, 25 could not be located and 70 died . The rest were excluded due to study design reasons. 2) Important baseline differences: None 3) Outcome of interest #1 After controlling for Head Injury, education and premorbid intelligence, the APOE genotype was associated with change in Symbol Digit Modalities Test (SDMT) F=3.20 and p= 0.041 and digit span backwards F= 3.14, p = 0.44. 4) Outcome of interest #2 After controlling for cofactors, education was not associated with change scores in any of the cognitive tests. 5) Outcome of interest #3 After controlling for cofactors, head injury was associated with change score in MMSE F = 4.91, p = 0.027 | Comments: There is no correction for multiple comparisons in this study therefore, they may be spurious findings. Head injury was assessed based on one self report question. This may not be an adequate measure of exposure. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: no 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Partial 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Partial 10) Analysis controls for confounding?: No 11) Analytic methods appropriate?: No
Christensen, Henderson, Korten, et al., 1997 | Geographical location: Canberra and Queanbeyan, Australia Setting: Community Study design: Prospective cohort Number of participants enrolled: 897 Duration of follow up: Mean 3.6 years, range 3.3 to 4.2 years Time from risk factor assessment to final cognitive assessment: Mean 3.6 years | Age: Range: 70 – 97 years Sex: [n (%)] Female: NR Male: NR Race/ethnicity: [n (%)] NR Baseline cognitive status: Non demented MCI Inclusion criteria: “sample of 897 elderly persons” Exclusion criteria: NR | Risk factor/exposure 1: Depression 2: Anxiety Method of assessing risk factor/exposure 18- item interview Goldberg Depression & Anxiety questionnaire; threshold for positive not specified Covariates/potential confounders adjusted for in analyses: Age Educational level Method(s) of assessing cognitive status: Mild cognitive impairment based on 4 criteria: 1. Report of neurological or other physical diseases causing cerebral dysfunction 2. Decline in cognition reported by subject or informant 3. >1.5 below mean on 2 of 12 cognitive tests 4. Met ICD-10 criteria for dementia or probable dementia, DSMIIR delirium or amnestic syndrome. Informant interview?: Yes, for some subjects | 1) Follow-up rate: 612/897=68% of total and 83% of those alive (124 died; 129 lost to f/u; 32 only informant data) 2) Important baseline differences: NR 3) Outcome of interest #1 Mild Cognitive Impairment (26 cases); multiple logistic regression analysis evaluating: age, education, anxiety, depression, only age was significantly associated with incident MCI- OR 1.09 per year (CI 1.01 to 1.18). Parameter estimates not given for other risk factors. | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort: No 2) Selection minimizes baseline differences in prognostic factors: Yes 3) Sample size calculated/5% difference: No 4) Adequate description of the cohort: No 5) Validated method for ascertaining exposure: Yes 6) Validated method for ascertaining clinical outcomes: Yes 7) Outcome assessment blind to exposure: Can’t Tell 8) Adequate follow-up period: Yes 9) Completeness of follow-up: No 10) Analysis controls for confounding: Partial 11) Analytic methods appropriate: Partial
Clarke, Birks, Nexo, et al., 2007 Oxford Healthy Aging Project | Geographical location: Oxford, United Kingdom Setting: Clinical – from general medical practice registry Study design: Prospective cohort Number of participants enrolled: 691 – analytical sample Duration of follow up: 10 years Time from risk factor assessment to final cognitive assessment: 8 years | Age: Mean (SD): 71.9 (5.2) for analytical sample Sex: [n (%)] Female: 60.4 Male: 39.6 Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Age aged 65 or older at baseline. Randomly selected from general practice registers for people living in Oxford city. Completed blood draw at Year 2 and completed MMSE year 1 and year 10. Exclusion criteria: Participants (n = 9) with extreme elevations of vitamin B-12 (>1000 pmol/L) or holoTC (>400 pmol/L) or who reported use of vitamin B-12 injections or any B-vitamin supplements (n=22) | Risk factor/exposure 1: B-12, folate, homocysteine, holotranscobalamin, methylmalonic acid Method of assessing risk factor/exposure 1: Direct measurement, non-fasting at year 2 Covariates/potential confounders adjusted for in analyses: Age Sex Smoking Vascular disease, Systolic blood pressure Education APOE Levels of other vitamins being assessed Method(s) of assessing cognitive status: Other – change in MMSE Informant interview?: No | 1) Follow-up rate: 691/1344 (51%), but not all of those gave blood 2) Important baseline differences: NR 3) Outcome of interest #1 Doubling in thcy was associated with a > 50% more rapid cognitive decline 4) Outcome of interest #2 Cognitive decline was not associated with serum concentrations of thcy after adj for other markers of vitamin status | Comments: Question 2 Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: Can’t Tell 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: No 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Comijs, Kriegsman, Dik, et al., 2009 LASA | Geographical location: 11 municipalities throughout the Netherlands Setting: Community Study design: Prospective cohort Number of participants enrolled: 2429 at baseline 1358 with complete data at 2 time-points were analyzed: T1 = 1294 data points T2 = 1296 data points T3 = 1016 data points Duration of follow up: 1993–1999 T1 = 1992/93 T2 = 1995/96 T3 = 1998/99 Time from risk factor assessment to final cognitive assessment: 6 yr | Age: Mean (SD): 72.1 (6.5) Range: 62–85 Sex: [n (%)] Female: 668 (51.6%) Male: 626 (48.4%) Race/ethnicity: [n (%)] NR Baseline cognitive status: NR (Referring to Knipscheer, 1995 – original article given at a congress and published in Dutch) Inclusion criteria: Member of cohort recruited for NESTOR- LSN study (Knipscheer, 1995) Age 50–85 Exclusion criteria: Born after 1930 Only one measurement time-point | Risk factor/exposure 1: presence of chronic disease – a) cardiac disease, b) peripheral artheroschlerosis, c)stroke, d) DM, e) COPD, f) arthritis, g) cancer. Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age, Sex Educational level Presence of comorbid disease outside of the 7 of interest Smoking Alcohol use Antidepressant meds Benzodiazepines Depressive sx (CES-D) Impaired vision Impaired hearing Mobility (6 AODL) Method(s) of assessing cognitive status: Other – Outcome 1: General Cognition -Mini-Mental State Exam (Folstein, 1975) O. 2: Fluid intelligence -Raven’s Colored Progressive Matrices (Raven, 1995) O.3: Processing speed - Alphabet Coding Task (Savage, 1984) O.4: Auditory Verbal Learning Test (Rey, 1964) Informant interview?: NR (but the interviews took place in the subject’s home) | 1) Follow-up rate: At T1 = 95.3% At T2 = 95.4% At T3 = 74.8% Follow-up rate for those eligible at baseline is uncertain 2) Important baseline differences: NR 3) Outcome of interest #1 General cognitive function over time: Negatively affected by DM (−0.49, CI −0.86/−0.11) 4) Outcome of interest #2 Fluid intelligence over time: Negatively affected by DM (−1.03, CI −1.54/−0.51) & stroke (−073, CI −1.32/− 0.14) 5) Outcome of interest #3 Information processing speed over time: negatively affected by PVD (−0.73, CI −1.43/−0.03), stroke (−1.97 CI −2.78/−1.16) and DM (−0.76, CI −1.53/0.00) 6) Outcome of interest #4 Memory performance (immediate and delayed recall) over time: Immediate- Negatively affected by DM (−0.44, CI −0.83/−0.06); positive association with cardiac disease (0.32, CI 0.11/0.52) Delayed – Negatively affected by DM (−0.65, CI −0.95/−0.17); positive association with cardiac disease (0.23, CI 0.005/0.45) and cancer (0.32, CI 0.08/0.67) Positive associations were the weakest reported; interactions showed faster rates of decline in immediate recall with PVD, information processing speed and memory with stroke, delayed recall with DM, and immediate recall with cancer. | Comments: Subjects who were excluded for insufficient data at after baseline were older, had less education, had limited vision, were more often women, and had lower test scores at baseline. Also, over F/U measurements, those measured with chronic disease increased from 29.9 to 52.8%, current smokers decreased and psychotropic drug use increased Generalized Estimated Equations take into account repeated measure and missing data (Twisk, 1997); also tested each potential cofactor before adding to the model and tested interactions Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Can’t Tell 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Partial, race not given 5) Validated method for ascertaining exposure?: Partial, self-report 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes at T2, no at T3 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Commenges, Scotet, Renaud, et al., 2000 Paquid Study | Geographical location: Gironde & Dordogne districts of France Setting: Community Study design: Prospective cohort Number of participants enrolled: 3777 in overall study but 1367 meet criteria for current analyses Duration of follow up: 2–5 yrs Time from risk factor assessment to final cognitive assessment: 2 – 5 yrs | Age: Mean (SD): 76 yr Sex: [n (%)] Female: 801 (59%) Male: 566 (41%) Race/ethnicity: [n (%)]NR Baseline cognitive status: Non-demented Inclusion criteria: ≥ 65 yr Living at home For current analyses- had to have completed nutrition questionnaire, not be demented at 3- yr fup, and have covariate info available, and were seen at one of the visits after 3-yr fup Exclusion criteria: Opposite of inclusion criteria | Risk factor/exposure 1: flavonoids Method of assessing risk factor/exposure 1: Self-report (2 different questionnaires for subsets of sample) Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Weight Vitamin C Method(s) of assessing cognitive status: DSM Informant interview?: No | 1) Follow-up rate: 1367 used in analyses. Difficult to assess follow-up rate because this is a subset of larger sample 2) Important baseline differences: NR 3) Outcome of interest #1 Flavonoid values in the upper 2 tertile-level were associated with lower rate of dementia (RR=0.49;0.26–0.92) | Comments: Question 1 Flavonoid quantities estimated from food frequency questionnaires and by imputing values using a “percentile method” – validity is uncertain Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Partial 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: Can’t Tell 4) Adequate description of the cohort?: Partial 5) Validated method for ascertaining exposure?: Partial 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Partial 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Cornelius, Fastborn, Winblad, et al., 2004 Kungsholmen Project | Geographical location: Stockholm, Sweden Setting: ] Community Study design: Prospective cohort Number of participants enrolled: 1301 Duration of follow up: Baseline 10/87 First follow up 91–93 Second f/up 94–96 Time from risk factor assessment to final cognitive assessment: nsaid exposure recorded baseline and first follow up. 2–9 years from time of risk factor assessment at baseline to final cognitive assessment | Age: Range: 74 – 85+ Sex: [n (%)] Female: 976 (75%) Male: 325 (25%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: All inhabitants of Kungsholman Parrish, Stockholm in Oct 1987 who were born in 1912 or before, including institutionalized residents. Unfortunately, I can’t tell how many were institutionalized. Exclusion criteria: it NR | Risk factor/exposure 1: nsaid Method of assessing risk factor/exposure 1: Self-report Inspection of pill bottles. Covariates/potential confounders adjusted for in analyses: Age Sex Underlying disease Educational level Method(s) of assessing cognitive status: DSM Informant interview?: Yes | 1) Follow-up rate: 50% at six years (approx) but only 3.5% due to drop-out; others demented or deceased so were not followed, 88% at first follow up 2) Important baseline differences: NR 3) Outcome of interest #1 ASA AD 1.34(0.96–1.89) 4) Outcome of interest #2 NSAIDs 0.61 (0.32–1.15) 5) Outcome of interest #3 ASA or NSAIDs 1.11 (0.81–1.52) 6) Outcome of interest #4 RR of AD with asa use if E4 negative: 1.80 (1.14–2.83) | Comments: Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Partial 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Dai, Borenstein, Wu, et al., 2006 Kame Project | Geographical location: King County, Washington Setting: Community Study design: Prospective cohort. Baseline, with 4 f/u waves 2 years apart. Number of participants enrolled: 1836 enrolled. Data from 1589 (86.5%) Duration of follow up: 6.3 yrs (SD 2.6) Time from risk factor assessment to final cognitive assessment: 6.3 yrs (SD 2.6) | Age: Mean (SD): 71.8 Sex: Female: 864 (54.4%) Male: 726 (45.6%) Race/ethnicity: Japanese American Baseline cognitive status: Non-demented Inclusion criteria: Japanese Americans (self-identified in the US Census) in King County, WA, aged ≥ 65 yrs Exclusion criteria: Dementia at baseline. | Risk factor/exposure 1: Dietary intake of a variety of foods Method of assessing risk factor/exposure 1: Self-report. Food frequency questionnaire. Each food item has 8 frequency options and 3 usual portion sizes. Intake of nutrients calculated from these data. 3 categories of frequency: 1) Less than weekly (reference) 2) 1–2 times/wk 3) ≥ 3 times/wk Risk factor/exposure 2: APOE status Method of assessing risk factor/exposure 2: Direct measurement on 1047 of the 1589 (65.9%) participants with complete food diaries Covariates/potential confounders adjusted for in analyses: Age, Dietary factors, Tobacco and alcohol, education, physical activity, APOE status Method(s) of assessing cognitive status: CASI to assess cognition at baseline and f/u. Further w/u if scored ≤87. Dx by Consortium to Establish a Registry for Alzheimer’s Disease criteria. NINCDS-ADRDA DSM-IV Informant interview?: Yes, using the Clinical Dementia Rating Scale | 1) Follow-up rate: Initial cohort of 3045 enumerated in a census, representing 90% of the Japanese American population in King County in 1990. Of these, 1985 (65.2%) participated in the baseline study, of whom 1836(60.3%) were dementia free and comprise the analytical sample. Of 1836 dementia-free participants, food intake data available from 1589 (86.5%) 2) Important baseline differences: NA 3) Outcome of interest #1 81 incident cases of probable AD, 63 of which completed the food diary and are included in the analyses. 4) Outcome of interest #2 HR for incident probable AD by frequency of intake [underlined: Fruit and vegetable juice:] 1) 1–2 x’s/wk: HR 0.84 (95% CI: 0.31– 2.29) 2) ≥3 x’s/wk: HR 0.24 (0.09–0.61) [underlined: Tea drinking:] 1) 1–2 x’s/wk: HR 1.49 (95% CI: 0.43– 5.16) 2) ≥3 x’s/wk: HR 1.70 (0.67–4.33) [underlined: Wine (sake) drinking:] 1) 1–2 x’s/wk: HR 0.49 (95% CI: 0.11– 2.10) 5) Outcome of interest #3 Author’s conclusions: “We found that frequent drinking of fruit and vegetable juices was associated with a substantial decrease of AD. This inverse association was stronger after adjustments for potential confounding factors.” | Comments: Fruit juice consumption was not an a priori hypothesis. This potential relationship with AD risk emerged after analysis of many different dietary factors. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes. Instrument validated on a separate sample. 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
de Lau, Smith, Refsum, et al., 2009 | Geographical location: Rotterdam, The Netherlands Setting: Community Study design: Prospective cohort Number of participants enrolled: 1019 Duration of follow up: 7 years 1995–96 assembled 2001–2003 Time from risk factor assessment to final cognitive assessment: 7 yr | Age: Mean (SD): 72.2 (7.4) Median: NR Range: 60–90 Sex: [n (%)] Female: 530 (52) Male: 489 (48) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Age, 60–90 y Exclusion criteria: Dementia blindness | Risk factor/exposure 1: Plasma B12 (and transport; metabolites transcobolamin and holotranscoboloamin, methylmalonic acid) Method of assessing risk factor/exposure 1: Microbial assay Covariates/potential confounders adjusted for in analyses: Age, sex, education, creat holoTC, homoCys, folate, DM, BP, Alcohol use, smoking, vitamin supplements, depression, intima- media thickness Method(s) of assessing cognitive status: Neuropsych tests to measure global cognitive function derived by combining z scores for all tests below- (Stroop test, Letter-Digit Substitution, Verbal fluency, Memory Scanning, memory function with 15-word verbal learning task for immediate and delayed recal Informant interview?: No | 1) Follow-up rate: 832/1019 (81.6%) 2) Important baseline differences: B12 deficiency associated with older age and white matter lesions on MRI 3) Outcome of interest #1 Follow-up cognition No association was observed for any of the studied variables (including plasma B12 analyzed by quintiles) with rate of cognitive decline during follow-up…data not shown. | Comments: Question 2 – no cat Dx Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes, stated as random 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Partial, race not given 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell, but probably yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Partial, no adjustment for multiple comparisons
DeKosky, Williamson, Fitzpatrick, et al., 2008 Ginkgo Evaluation of Memory Study | Geographical location: 4 US academic medical centers (MD, PA, CA, & NC) Setting: Community Study design: RCT Test intervention: Twice-daily doses of 120-mg G bilboa extract (EGb 761; Schwabe Pharmaceuticals) Number of participants enrolled: 3069 Duration of follow up: Median 6.1 yrs Time from risk factor assessment to final cognitive assessment: median follow-up was 6.1 yrs (max = 7.3 yrs) | Age: Mean (SD): 79.1 (3.3) Sex: [n (%)] Female: 46% Male: 54% Race/ethnicity: [n (%)] White 2930 (95%) Nonwhite 139 (5%) Baseline cognitive status: Normal MCI Inclusion criteria: Aged 75 or older, on voter registration list or purchased mailing list; have willing proxy to be interviewed every 6 mos Exclusion criteria: Prevalent dementia (meeting DSM-IV criteria for dementia or a score >0.5 on the CDR; currently taking warfarin; taking cholinesterase inhibitors for cognitive problems or dementia; unwilling to discontinue taking over-the-counter G bilboa for the duration of study; currently being treated with tricyclic antidepressants, antipsychotics, or other medications with significant psychotropic or central cholinergic effects; daily use of more than 400-IU vitamin I or unwillingness to reduce intake to this level; history of bleeding disorders; hospitalization for depression within the last yr or electroconvulsive therapy within last 10yrs; history of Parkinson disease or taking anti-Parkinson medications; abnormal thyroid tests, serum creatinine level greater than 2.0 mg/dL, or liver function tests more than 2 times the upper limit of normal at baseline; baseline vitamin B12 levels 210 pg/mL or lower; hematocrit level less than 30%; platelet count lower than 100×103/μL; disease- related life expectancy of less than 5 yrs; known allergy to G bilboa | Risk factor/exposure 1: ginkgo biloba Method of assessing risk factor/exposure 1: Direct measurement Covariates/potential confounders adjusted for in analyses: Age Race Sex MCI APOE Cardiovascular disease Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Informant interview?: Yes | 1) Follow-up rate: 379 died – not sure from which groups. States knew cognitive status of 93.6% participants at trial end. 1426/1524 placebo 1448/1545 GB 2) Important baseline differences: none 3) Outcome of interest #1 No difference in rate of AD by intervention for all participants No difference in rate of AD by intervention for baseline normal group No difference in rate of AD by intervention for baseline MCI group 4) Outcome of interest #2 No interaction by age, sex, or MCI for results in 3) above by | Comments: None Quality assessment: For RCTs: 1) Baseline comparability?: Yes 2) Valid AD/cognitive outcomes assessment?: Yes 3) Subjects/providers blind?: Yes 4) Outcome assessors blind?: Yes 5) Incomplete data adequately addressed?: Yes 6) Differential dropout rate < 10%?: Yes 7) Overall dropout rate < 30%?: Yes 8) Conflict of interest reported and insignificant?: Yes 9) Randomization adequate?: Yes 10) Allocation concealment adequate?: Yes
Devore, Grodstein, van Rooij, et al., 2009 Rotterdam Study Dietary consumption of fish and omega-3 PUFA’s in relation to long-term risk of dementia | Geographical location: Ommoord (Rotterdam), Netherlands Setting: Community Study design: Prospective cohort Number of participants enrolled: 5395 Duration of follow up: 9.6 years Time from risk factor assessment to final cognitive assessment: 14 years | Age: Mean (SD):8.2 Range: 67 – 88.3 Sex: [n (%)] Female: 3184, 59% Male:2211, 41% Race/ethnicity: NR Baseline cognitive status: Non-demented Inclusion criteria: Participants in the Rotterdam study, aged ≥ 55 years who were free of dementia and reported dietary information at baseline Exclusion criteria:<br>-Questionable cognitive status (score of <80 on the Cambridge examination of mental disorders of the elderly, Camdex) -living in a nursing home -lack of reliable dietary information | Risk factor/exposure1: Consumption of fish and omega-3 polyunsaturated fatty acids (PUFAs) Method of assessing risk factor/exposure1: Self-report2-step protocol consisting of home interview and a validated semi-iquantitative food-frequency questionnaire administered by a trained dietician at the time of clinicalexamination. Covariates/potentialconfoundersadjusted for in analyses: -Age -Sex -Education -Total energy intake -Alcohol intake -Smoking -Body mass Index(BMI) -High total cholesterol -Hypertension -Dietary intake of Vitamin E -Supplement use(either fish, omega-3, or antioxidant supplements) -History of stroke, myocardial infraction, or type 2 diabetes Method(s) of assessing cognitive status: DSM Dementia assessed by 3 step protocol: 1. Combined Mini-Mental State Examination (MMSE) and Geriatric Mental State Schedule (GMS) 2. Camdex examination for those with MMSE scores<26 or GMS scores>0 3. Evaluation by neurologist and neuropsychologist Final diagnosis made by panel consisting of neurologist, neuropsychologist and research physician according to DSM-III- R;NINCDS-ADRDA for AD Informant interview?: No | 1) Follow-up rate: 5395/6444=83.7.5% - Of the 7963 individuals who agreed to participate, 7046 underwent cognitive screening and were free of dementia. 6444 eligible for dietary history -Final population for analysis = 5395 2) Important baseline differences: -Participants with greater fish intake also tended to consume more alcohol 3) Outcome of interest #1 - Dementia developed in 465 participants (365 with diagnosis of AD) -Total fish and omega-3 PUFA intake unrelated to AD risk. HR for high(>sex-specific median) intake 0.99(0.76–1.29), low intake HR 1.05(0.83–1.37) compared to no intake No association between quartiles of long chain omega-3 fatty acid intake(p=0.7 for trend), EPA (p=0.7 for trend) or DHA (p=0.9 for trend). | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Partial 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Devore, Kang, Okereke, et al., 2009 Nurses Health Study Participants Physical activity levels and cognition in women with type 2 diabetes | Geographical location: USA (participants dispersed across several states in the US) Setting: Community Study design: Prospective cohort Number of participants enrolled: 1550 Duration of follow up: 4 years Time from risk factor assessment to final cognitive assessment: 4 yrs | Age: Mean (SD):74(2.3) Sex: Female: 1550 (100%) Male: 0 (0%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-Demented Inclusion criteria: Nurses Health Study participants, aged ≥ 70 with type 2 diabetes. (Nurses health study is a long-running study of registered nurses that started in 1976 with recruitment of 121,700 nurses between ages 30–55yrs) Exclusion criteria: -Women unable to walk -Women diagnosed with Parkinson’s or Alzheimer’s disease prior to initial cognitive assessment -Women who did not report information on specific disability indicators (15%) (osteoarthritis, chronic bronchitis, fatigue, balance problems, moderate-to-severe body pain, and limitations in walking) | Risk factor/exposure1: Physical activity levels Method of assessing risk factor/exposure1: Self-report: Self reports of physical activity converted into metabolical equivalent hours per week (MET-hr) (e.g. MET for sitting=1, for running=12, for stair climbing=8 and so on) MET multiplied by hours per activity and summed over all activities gives energy expenditure per week.) based on average of 5 reports over a median of 13.3 years Covariates/potential confounders adjusted for in analyses: Age, education, baseline cognitive status, disability indicators(osteoarthritis, chronic bronchitis, fatigue, balance problems, moderate-to-severe body pain, and limitations in walking) Method(s) of assessing cognitive status: Battery of 6 cognitive tests administered by trained nurses via telephone; starting with telephone interview of cognitive status (TICS) and including, East Boston Memory Test-immediate and delayed recall, Category Fluency, delayed recall of 10 word list and digit span backward. Assessment expressed in terms of general cognition and verbal memory; general cognition obtained by averaging all 6 tests; verbal memory score obtained by averaging 4 tests: immediate and delayed recalls of East Boston Memory Test and Telephone interview of Cognitive Status 10-word list. Baseline interview followed by 3 interviews over a 4 year period. Informant interview?: No | 1) Follow-up rate: -1550 women analyzed for cognitive decline across 3 interviews over 4 yrs; >90% follow-up. 2) Important baseline differences: Differences in self-reported physical disability across increasing tertiles of physical activity 3) Outcome of interest #1 Mean difference in change in cognitive function scores by tertile of average physical activity Adjusted for age, education and baseline cognitive status, women with greater levels of long-term physical activity associated with less cognitive decline on TICS, global and verbal cognition; however this finding was not statistically significant when adjusted for disability indicators. | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5%difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Partial 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Dik, Jonker, Bouter, et al., 2000 LASA study | Geographical location: Amsterdam, The Netherlands Setting: LASA: Community Study design: Prospective cohort Number of participants enrolled: LASA: 3107 enrolled. 1551provided blood. 1297 genotypes; Excluded 54 excluded because MMSE <21. Total 1243 participated Duration of follow up: LASA: mean of 3.1 years Time from risk factor assessment to final cognitive assessment: Average 3.1 years (SD0.2) | Age: Mean (SD): Equal numbers in 5 year intervals from 55 to 85. Only subjects>62 in this study. Range: ≥62 to 85 Sex: [n (%)] Female: Male: Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Age ≥ 62 MMSE ≥ 21 Exclusion criteria: | Risk factor/exposure1: APOE E4 genotype Method of assessing risk factor/exposure1: genotyping Covariates/potential confounders adjusted for in analyses: Age Sex Educational level E4 carriers E4 non carriers MMSE 27–30 (normal cognition) MMSE 21–26 (impaired cognition) Method(s) of assessing cognitive status: MMSE; AVLT (3 trials); memory decline was defined as ≥ 1 SD mean change score on IR, DR and retention based on AVLT. Informant interview?: No | 1) Follow-up rate: 876/1243 = 70.5% Death 13.5%; refusal 11.1%; frailty 4.4%; loss of contact 0.5%.22 subjects lost data leaving 854 with testing at both time points. Loss to follow-up was associated with older age, lower education and lower scores on all cognitive measures (p<.001). No association between follow-up and APOE genotype. Important baseline differences: NR Outcome of interest #1 APOE E4 is a risk factor for memory decline only in cognitively impaired individuals (MMSE 21–26), not in cognitively normal subjects (MMSE ≤ 27). In Subjects with MMSE 21–26 And APOE E4 (adjusted for age, sex, education and baseline recall scores) OR decline on IR 3.8 (95% CI 1.4–10) OR decline on DR 2.9 (1.2–7.0) OR decline on retention 3.3 (1.1–10.1). No association of decline in cognitively normal subjects with APOE E4. Outcome of interest #2 Subjects with MMSE 21–26 and age >75 and APOE E4 OR decline on IR 4.5 (1.4–13.8) OR decline on DR 3.6 (1.2–10.8) OR decline on retention 6.6 (1.5–29.7) | Comments: APOE E4 is a risk factor for memory decline only in cognitively impaired individuals (MMSE 21–26), not in cognitively normal subjects(MMSE ≤ 27). Cognitively impaired subjects with APOE E4 who are >75 years of age are at particularly increased risk for decline. Quality assessment: For observational studies: 1) Unbiased selection of the cohort: Yes 2) Selection minimizes baseline differences in prognostic factors: Yes 3) Sample size calculated/5%difference: No 4) Adequate description of the cohort: Yes 5) Validated method for ascertaining exposure: Yes 6) Validated method for ascertaining clinical outcomes: Yes 7) Outcome assessment blind to exposure: Can’t Tell 8) Adequate follow-up period: Yes 9) Completeness of follow-up: Partial 10) Analysis controls for confounding: Yes 11) Analytic methods appropriate: Yes
Dodge, Zitzelberger, Oken, et al., 2008 | Geographical location: Oregon, US Setting: [ Community –mailing to age-eligible in community and research in university aging and AD center Study design: RCT Test intervention: Standardized GBE (80mg 3x daily) Comparator intervention(s): placebo Number of participants enrolled: 118 Duration of follow up: 42 mo Time from risk factor assessment to final cognitive assessment: 42 mo was the aim – in reality ave 3.0 (0.98) yr for placebo and 3.3 (0.77) yr for GBE | Age: Mean (SD): 87.5 yr (2.14–2.22) Range: 85–94.1 yrs Sex: [n (%)] Female: 71 (60% Male: 47 (40%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Normal Inclusion criteria: Age > 84 yrs; no subjective complaint of memory impairment compared to others of their own age; has not sought assessment for memory or cognitive dysfunction; normal memory function defined by an education adjusted score on the Logical Memory Subscale of the Wechsler Memory Scale-Revised; Mini0Mental State Examination score>23; Blessed Orientation Memory Concentration Test<12; Functionally independent (ADL=0); Clinical Dementia Rating = 0; Absence of significant depressive symptoms (CES-D-10 score <4); Sufficient vision and hearling to complete all testing; sufficient English language skills to complete all testing; general health status that will not interfere with ability to complete longitudinal study; informant available with frequent contact with subject to verify functional status Exclusion criteria: Diseases associated with dementia such as AD, ischemic vascular dementia, normal pressure hydrocephalus, or Parkinson disease; significant disease of the CNS such as brain tumor, seizure disorder, subdural hematoma, cranial arteritis; current (within last 2 yrs) alcohol or substance abuse according to DSM-IV criteria; abnormal laboratory values indicating B12 deficiency, thyroid disease, or urinary tract infection(documented chronic bacterial colonization is acceptable); unstable or significantly symptomatic cardio vascular disease such as CAD with frequent angina, or CHF with shortness of breath at rest; insulin dependent diabetes mellitus; active systemic CA within 5 yrs of study entry(Gleason Grade <3 prostate CA, and non- metastatic skin CA are acceptable); illness that requires >1 visit per mo to clinician; progressive vision loss; need for oxygen supplementation for adequate function; frequent use of high doses of analgesics; sedative medications except for those used occasionally for sleep; subjects taking CNS- active medications that have not been on stable doses for at least 2 mos including cimetidine, beta- blockers, and selective serotonin reuptake inhibitors; subjects taking neuroleptics, antiparkinsonian agents, systemic corticosteroids, and narcotic analgesics; Subjects will NOT be excluded if they are taking other over-the-counter supplements, but the dose must not be changed during the course of the trial unless medically indicated; Subjects taking cholinesterase inhibitors; use of investigational drugs within 5 half-lives prior to baseline | Risk factor/exposure1: RCT – Ginkgo biloba extract Method of assessing risk factor/exposure1: Direct measurement of number of pills taken Covariates/potential confounders adjusted for in analyses: Covariates used in secondary analyses Age Sex Educational level Baseline MMSE score Adherence to intervention medication Depression APOE # prescriptions Cumulative illness scale Living arrangement Method(s) of assessing cognitive status: Other – change in CDR from 0.0 to 0.5 Some analyses examined decline in delayed recall task – but description of these results are not clear Informant interview?: Yes | 1) Follow-up rate: 79/118 (66.9%) 2) Important baseline differences: None 3) Outcome of interest #1 In unadjusted model, no difference in conversion to CDR = 0.5 for GBE vs placebo group. 4) Outcome of interest #2 When adjust for adherence to intervention, GBE group at lower risk of converting to CDR = 0.5. Effect remains when all other covariates added. 5) Outcome of interest #3 GBE does not have an effect on delayed recall test over time (not sure if this is change in score or what) | Comments: Used proportional hazards models. Appeared to include everyone until the point of drop out (death, drop-out due to stroke etc). This may account for some bias created by the ~30% attrition? Quality assessment: For RCTs: 1) Baseline comparability?: Yes 2) Valid AD/cognitive outcomes assessment?: Yes 3) Subjects/providers blind?: Yes 4) Outcome assessors blind?: Yes 5) Incomplete data adequately addressed?: No 6) Differential dropout rate <10%?:No, closer to 12% 7) Overall dropout rate < 30%?:No 30–35% 8) Conflict of interest reported and insignificant?: Can’t Tell, funding source not given, does state source of drug 9) Randomization adequate?: No, statistically matched 10) Allocation concealment adequate?: Can’t Tell
Doody, Ferris, Salloway, et al., 2009 (Aricept) | Geographical location: U.S.A, multicenter Setting: NR Study design: RCT with 3-week placebo run-in phase Test Intervention: Donepezil 5mg daily *6 weeks, then 10mg daily Comparator: Intervention: Placebo Number of participants enrolled: 821 randomized; 778 analyzed Duration of follow up: years 48 weeks | Age: Mean (SD):70.2 (9.71), 69.8 (10.32) Sex: [n (%)] Female: 354 Male: 424 Race/ethnicity: [n (%)] Caucasian 676 (87%) Baseline cognitive status: Amnestic MCI Inclusion criteria: Age 45–90 Memory complaint corroborated by an informant MCI defined by: CDR0.5 with memory box score 0.5 or 1.0 and <=2 other boxes >=1; MMSE 24–28; Logical Memory II delayed Paragraph recall ≤ 8 (education ≥ 16 years), ≤ 4 (8–15 years educ), ≤ 2(≤ 7 years educ); modified Hachinski Ischemia scale score ≤ 4; an informant; brain imaging w/in 12 months without infarction or focal lesions. Exclusion criteria: Dementia Neurologic or psychiatri disorder Sleep disorder that could affect cognition Alcohol abuse/dependence w/in 5 years Uncontrolled HTN or DM Any other medical condition incompatible with study participation Past treatment with ChEI or memantine for > 1 month or within 3 months of study screening Concomitant anticholinergics, anticonvulsants, antiparkinsonian agents, stimulants, cholinergic agents, antipsychotics or antidepressants or anxiolytics with anticholinergic or procholinergic effects. | Covariates/potential confounders adjusted for in analyses: [delete any from the list below that do not apply and add items as needed] Age Educational level Method(s) of assessing cognitive outcomes: [delete all that do not apply] Primary: Modified ADAS-Cog (0–89 point scale, 13 subtests) and CDR sum of boxes (0–18; 6 subscales each rated 0–3; CDR-SB) Secondary: MMSE Symbol Digit Modalities Test Digit Span Backwards tst Pereived Deficits Questionnaire (PDQ) PDQ for relatives Neuropsychiatric Inventory Patient Global Assessment Clinical Global Impression of Change- Mild Congitive Impariement Informant interview?: No | 1) Follow-up rate: 499/821 randomized = 60.8% 499/778 analyzed = 64.1% Mean exposure rate to treatment Donepezil = 248 (120) days Placebo = 282 (100) days 2) Important baseline differences: No, comparable at baseline 3) Outcome of interest #1 Analyzed by analysis of covariance using last observation carried forward (mean difference = (baseline– follow-up)donepezil – (baseline –follow-up)placebo ADAS-Cog: mean difference at f/u =−0.90 (SE 0.37), p=0.01 favoring donepezil CDR-SB, mean difference not given; no statistically significant difference 4) Outcome of interest #2 Mean change from baseline to endpoint on 8 cognitive measures Of 8 secondary measures, donepezil treated subjects showed statistically significant benefit on two: Perceived Deficits Questionnaire: − 1.8 (0.8)donepezil vs. −0.2 (0.7) placebo Patient Global Assessment: 3.3 (0.1) donepezil vs. 3.5 (0.1) placebo 5) Outcome of interest #3 Discontinuation due to adverse event 72 (18.4%) donepezil vs. 32 (8.3%) placebo Any adverse event: 318 (81.3%) donepezil vs. 267 (69.0%) placebo; most common – diarrhea (16.4% vs. 3.4%), muscle spasms (13.3% vs. 1.8%) and nausea (9.7% vs. 4.4%) Serious adverse event: 48 (12.3%) donepezil vs. 41 (10.6%) placbo Deaths: 3 donepezil, (lymphoma, sudden death, lung cancer) 1 placebo (pleural mesothelioma) – all judged to be unrelated to study medication | Comments: None Quality assessment: For RCTs: 1) Baseline comparability?: Yes 2) Valid AD/cognitive outcomes assessment?: Yes 3) Subject/providers blind?: Can’t Tell; “double-blind” but who is blind is not described 4) Outcome assessors blind?: ?: Can’t Tell; “double-blind” but who is blind is not described 5) Incomplete data adequately addressed?: No, used LOCF 6) Differential dropout rate ≤ 10%?:No 7) Overall dropout rate ≤ 30%?: No 8) Conflict of interest reported and insignificant?: Yes, funded by industry, investigators, including analysts employed by sponsor 9) Randomization adequate?: Yes 10) Allocation concealment adequate?: Can’t Tell
DuFouil, Alperovitch, Ducros, et al., 2003 EVA | Geographical location: Nantes, France Setting: Community Study design: Prospective cohort Number of participants enrolled: 1241 Duration of follow up: With a population of 1241 at baseline, 1151 followed up for 2 yrs, 986 for 3 years, 782 for four years OR for homocysteine calculated for 2 yr change in mmse Time from risk factor assessment to final cognitive assessment: blood drawn at baseline, cog testing each time subject returned. | Age: Mean (SD): 67 (3.0) Range: 61–73 Sex: [n (%)] Female: 58.6% Male: 41.4% Race/ethnicity: [n (%)] NR Baseline cognitive status: doesn’t look like they eliminated the impaired but mean mmse high at baseline Inclusion criteria: Homocysteine measured at baseline 2 year f/u completed Exclusion criteria: NR | Risk factor/exposure 1: homocysteine Fasting plasma stored unkn length of time Method of assessing risk factor/exposure 1: Direct measurement Covariates/potential confounders adjusted for in analyses: age, gender, education, baseline cognition, bmi, etoh, smoking, htn, hyperchol, glycemic status, hx of vascular dz, folate, vit B12 concen. Method(s) of assessing cognitive status: change in test scores (MMSE, Trails B, Digit symbol substitution test, Finger tapping) Informant interview?: No | 1) Follow-up rate: With a population of 1241 at baseline, 1151 followed up for 2 yrs, 986 for 3 years, 782 for four years 1107/1241 (89%) in cognitive decline analysis 2) Important baseline differences: In the higher class of hcy, subjects were older, more men, more ETOH, and more likely to have htn, dm, and lower folate levels Overall, lower cognitive performance in those with higher homocysteine. 3) Outcome of interest #1 cognitive deterioration defined as mmse decrease of 3 or more pts in two years (118 out of 1107 with 2 year f/u). OR 2.8 (1.2 – 6.2) for highest hcy group (>15 umol/l) vs lowest hcy group (<10 umol/l) Stratified analysis by HTN, B12, folate, h/o vascular disease, glycemic status, and cholesterol status did not show any interaction between these factors and homocysteine. 4) Outcome of interest #2 Change in cognition evaluated as a continuous measure. Statistically significant greater decline on 3 of 4 outcomes (MMSE, Finger tapping, DSST) for highest homocysteine vs. lowest. Comparison of 2^nd^ and 3^rd^ highest homocysteine vs lowest groups did not show a statistically significant difference. | Comments: Question 2 Population was 61–73 years old at baseline and likely included some impaired subjects but baseline mmse was 27.6 with a mean age of 67 (3.0) Appears that homocysteine categories determined post-hoc based on data and not based on theorectical or a priori thresholds Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Partial, MMSE decline of 3 points of unknown clinical significance 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Dufoil, Fuhrer, Dartigues, et al., 1996 PAQUID Study | Geographical location: Gironde, France Setting: Community Study design: Prospective cohort Number of participants enrolled: 2792 overall; 2726 in this analysis Duration of follow up: 3 years Time from risk factor assessment to final cognitive assessment: 3 years | Age: Range: ≥ 65 years Sex: [n (%)] Female: 1632 (59.9%) Male: 1094 (40.1%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Age >=65 Cognitive assessment at baseline and follow-up Exclusion criteria: Dementia | Risk factor/exposure 1: Depression (CESD >16 for men and >22 women) Method of assessing risk factor/exposure 1: Self-report at baseline and 3 year f/u Covariates/potential confounders adjusted for in analyses: Age emsp;Sex Educational level Marital status IADL Baseline cognition Method(s) of assessing cognitive status: MMSE decline >= 5 points Informant interview?: No | 1) Follow-up rate: 1600 of 2726 (59%); 800 refused, 311 died, and 15 lost to follow-up 2) Important baseline differences: Not given Logistic Regression Analysis 3) Outcome of interest #1 Incidence of cognitive impairment defined by MMSE decline >=5 points. (48 subjects) CESD > threshold at baseline; OR 0.8 (95% CI 0.3 to 2.1) Sensitivity analysis to evaluate the effects of subjects lost to follow-up showed no association between depressive symptom and cognitive impairment until assuming a 10% rate of cognitive impairment in depressive non-respondents (compared to an observed rate of 2.8% in depressed respondents) 4) Outcome of interest #2 Change in MMSE (F/U – Baseline) was associated with change in CESD scores; adjusted estimate Beta=− 0.026 (95%CI −0.039 to −0.013) 5) Outcome of interest #3 Mean change +0.3 (2.6) | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort: Yes 2) Selection minimizes baseline differences in prognostic factors: Yes 3) Sample size calculated/5% difference: No 4) Adequate description of the cohort: Yes 5) Validated method for ascertaining exposure: Yes 6) Validated method for ascertaining clinical outcomes: Yes 7) Outcome assessment blind to exposure: Can’t Tell 8) Adequate follow-up period: Can’t Tell 9) Completeness of follow-up: No 10) Analysis controls for confounding: Yes 11) Analytic methods appropriate: Yes
Dullemeijer, Durga, Brouwer, et al., 2007 FACIT | Geographical location: Wageningen, Netherlands Setting: NR Study design: Secondary analyses of an RCT arm Number of participants enrolled: 404 subjects in this analyses Duration of follow up: 3 yrs Time from risk factor assessment to final cognitive assessment: 3 yr | Age: Mean (SD): 60 (6.0) Sex: [n (%)] Female: 117 (29) Male: 287 (71) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented (assume because part of RCT and also young age of sample) Inclusion criteria: Participants in FACIT, a randomized placebo- controlled trial of folic acid supplementation on cognitive performance, carotid intima-media thickness, and hearing. Men and postmenopausal women aged 50–70 Plasma total homocysteine concentrations:≥ 13 micromol/L and ≤ 26 micromol/L and serum vitamin B-12 concentrations ≥ 200 pmol/L. Exclusion criteria: NR | Risk factor/exposure 1: n-3 fatty acid Method of assessing risk factor/exposure 1: Direct measurement Method of assessing risk factor/exposure 2: Self-report Proxy report Direct measurement Medical record Other Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Baseline cognitive status Erythrocyte folate ETOH use Method(s) of assessing cognitive status: Other – used standardized test scores at baseline and 3 yr follow-up in 5 domains Informant interview?: No | 1) Follow-up rate: 404/408 (2 that did not return for fup had died) 2) Important baseline differences: NR by exposure group 3) Outcome of interest #1 Higher plasma n-3 PUFAs predicted less decline over 3 yr in domains of sensorimotor speed (p = 0.02) and complex speed (<0.01), but domains of memory, information processing speed, and word fluency showed no sig association with n-3 PUFAs | Comments: Question 2 This paper has a nice table (Table 5) of other longitudinal studies assessing n-3 PUFAs. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: Can’t Tell 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Engelhart, Geerlings, Ruitenberg, et al., 2002 Rotterdam Study | Geographical location: Rotterdam, Netherlands Setting: Community Study design: Prospective cohort Number of participants enrolled: 5395 Duration of follow up: Mean 6 yr Time from risk factor assessment to final cognitive assessment: Mean 6 yr | Age: Mean (SD): 67.7 (7.8) Sex: [n (%)] Female: 3183 (59) Male: 2212 (41) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: ≥ 55 yr; resident of specific suburb in Rotterdam, had reliable nutritional data, not demented at baseline Exclusion criteria: Nursing home residents | Risk factor/exposure 1: anti-oxidant intake Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Baseline cognitive status ETOH use Smoking BMI Total energy intake Presence of carotid plaques Supplemental antioxidant use Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Informant interview?: Yes | 1) Follow-up rate: authors note f/u for dementia was 99.9% - but there were exclusions from analytical sample for other reasons—can not determine overall f/u – but in general appears to be adequate 2) Important baseline differences: NR 3) Outcome of interest #1 Fully adjusted model, Vit C associated with reduced risk of incident AD (RR-0.82; 0.68–0.99) 4) Outcome of interest #2 Fully adjusted model, Vit E borderline association with reduced risk of incident AD (RR-0.82; 0.66–1.00) 5) Outcome of interest #3 Fully adjusted model, beta carotene (RR-0.87; 0.70–1.09) and flavonoids (RR-0.99; 0.83–1.18) not associated with reduced risk of incident AD | Comments: Question 1 Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: No 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Evans, Hebert, Beckett, et al., 1997 NIA EPESE study (Established Populations for Epidemiologic Studies of the Elderly) | Geographical location: East Boston, MA Setting Community Study design Prospective cohort Number of participants enrolled: 642 enrolled. This number was a stratified random sample drawn from a cohort of Duration of follow up: 4.3 years Time from risk factor assessment to final cognitive assessment: 4.3 years | Age: Mean (SD): NR Range: 65–80+ years Sex: Female:362(56.4%) Male: 280(43.6%) Race/ethnicity: NR Baseline cognitive status: Non-demented Inclusion criteria: 65+ years old, non- demented, community resident. Exclusion criteria: NR | Risk factor/exposure 1: years of formal schooling Method of assessing risk factor/exposure 1: Self-report Risk factor/exposure 2 Level of occupational status Method of assessing risk factor/exposure 2: Self-report ”Occupations were coded according to perceived prestige.” Covariates/potential confounders adjusted for in analyses Age Sex F/u interval For combined logistic regression model, Occupational prestige score and income were also included. Method(s) of assessing cognitive status All participants underwent clinical evaluation. NINCDS-ADRDA Informant interview No | 1) Follow-up rate: Initial prevalence study of 3623 residents. 2313 free of AD. Excluded 177 with poor or intermediate memory performance. Sample = 2136 303 died, 409 did not participate. Stratified random sample of 642 of remaining 1601 persons (79.6%) in analytical sample. 2) Important baseline differences: NA 3) Outcome of interest #1— probable AD 95 with incident probably AD. Fewer years of education (OR 0.83; 95% CI: 0.75, 0.92), lower occupation prestige (OR 0.96, 95% CI: 0.93,0.99) and lower income are associated with increased risk of probable AD In the logistic regression analysis of risk of incident clinically diagnosed AD, odds ratio compared to the rest of the population was 0.85 (0.75– 0.95). | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Partial 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Everson- Rose, Mendes de Leon, Bienias, et al., 2003 Chicago Health and Aging Project (CHAP) | Geographical location: Chicago, IL Setting: Community Study design: Prospective cohort Number of participants enrolled: 4398 Duration of follow up: Mean: 5.3 yrs Time from risk factor assessment to final cognitive assessment: Mean: 5.3 yrs | Age: Mean (SD): 73.9 (6.4) Sex: Female: 2731 (62.1%) Male: 1667 (37.9%) Race/ethnicity: Black: 2713 (61.7%) Non-Black: 1685 (38.3%) Baseline cognitive status: NR. No exclusion for dementia. Inclusion criteria: In CHAP study. Age ≥ 65 yrs, living in south side of Chicago. Must have had tests of cognitive function from at least 2 of 3 interviews. Exclusion criteria: NR | Risk factor/exposure 1: Socieconomic position (SEP). Method of assessing risk factor/exposure 1: Self-report. Composite index: parental educational attainment and occupational prestige and self-reported family financial status as a child. Risk factor/exposure 2: Childhood cognitive milieu. Method of assessing risk factor/exposure 2: Self-report. Composite index of 3 questionnaires: frequency of someone in household having been read to, told stories to, or played games with as a child. Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Interactions of time with childhood Method(s) of assessing cognitive status: Global cognitive index, derived from measures of memory, perceptual speed. Symbol Digit Modalities Test; recall portions of the East Boston Story; MMSE. Informant interview?: No | 1) Follow-up rate: 6158 in CHAP study. 1175 died before f/u, 149 relocated, 341 refused, 34 could not be contracted, and 61 were missing for other reasons. 4398 in this study (71.4% of eligible) 2) Important baseline differences: NA 3) Outcome of interest #1 SEP: Each 1-unit increase in childhood SEP associated with a 0.158-standard unit higher level of cognitive function (95% CI: 0.130, 0.186, p<0.0001). 4) Outcome of interest #2 Cognitive milieu: Each 1-unit increase in childhood SEP associated with a 0.055-standard unit higher level of cognitive function (95% CI: 0.039,0.070, p<0.0001). 5) Outcome of interest #3 Neither SEP (β = −0.003, 95% CI: − 0.009, 0.003; p=0.32) nor cognitive milieu (β= =−0.001, 95% CI: −0.004, 0.002, p=0.39) was associated with cognitive change over time. | Comments: None. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: Can’t Tell 4) Adequate description of the cohort?: Partial 5) Validated method for ascertaining exposure?: Partial, conceptually sensible but no citation for validity. 6) Validated method for ascertaining clinical outcomes?: Yes. 7) Outcome assessment blind to exposure?: Can’t Ttell. 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Feart, Samieri, Rondeau, et al., 2009 Three-City (3C) study | Geographical location: Bordeaux, France Setting: Community Study design: Prospective cohort Number of participants enrolled: 1524 enrolled; 1410 analyzed Duration of follow up: 7 years Time from risk factor assessment to final cognitive assessment: 7 years | Age: Mean (SD): 75.9 Range: 67.7–94.9 Sex: [n (%)] Female: 883,62.6% Male: 527,37.4% Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: -65 years or older Exclusion criteria: -Dementia at baseline | Risk factor/exposure 1: Mediterranean Diet Method of assessing risk factor/exposure 1: Self-report; Based on food frequency questionnaire administered by a specifically trained dietician, frequency of consumption of 40 categories of food and beverages for all meals were recorded and food groups considered to be part of Mediterranean diet were identified and adherence to the diet rated on a 0 to 9 scale. Covariates/potential confounders adjusted for in analyses: Age, Sex, Education, Marital Status, Energy Intake, Physical Activity, Depressive symptomatology, Taking 5 medications or more, Apolipoprotein E genotype, Cardiovascular risk factors, Stroke Method(s) of assessing cognitive status: DSM 4 neuropsychological tests administered by trained psychologists: 1. Mini Mental State Examination (MMSE) 2. Isaacs Set Test (IST) 3. Benton Visual Retention Test (BVRT) 4. Free and Cued Selective Reminding Test (FCSRT) Diagnosis of dementia based on 2 Stage procedure First stage: Neurological exam by a neurologist Second stage: Review of potential cases of dementia by independent committee of neurologists with in depth assessment of medical history of each participant to obtain consensus on diagnosis and etiology according to criteria of the Diagnostic and Statistical Manual of Mental Disorders. Informant interview?: No | 1) Follow-up rate: 1213/1524= 79.6% 1524 enrolled; 1410 participants without dementia had at least 1 follow-up; 1213 participants examined at the end of the 3^rd^ and final follow-up exam. 2) Important baseline differences: Greater Mediterranean diet adherence was associated with male sex and being married but not with education, income or physical activity Individuals in the middle or high Mediterranean diet score categories had a lower mean BMI and higher mean energy intake than those in the lowest category 3) Outcome of interest #1 Main outcome measure was cognitive performance on the 4 neuropsychological tests. Higher Mediterranean diet score associated with fewer MMSE errors (β=−0.006; 95%CI, −0.01 to −0.0003; P=0.04 for 1 point of the Mediterranean diet score) and therefore slower MMSE cognitive decline but this was not consistently the case with other cognitive tests. Among the subgroup who did not develop dementia, higher Mediterranean diet score associated with fewer MMSE errors and less decline on the FCSRT 4) Outcome of interest #2 99 incident cases of dementia 66 probable or possible cases of Alzheimer disease High Mediterranean diet score (6–9) HR 1.12 (0.60–2.10) nor middle scores (4–5) HR 1.11 (0.63–1.94) compared to low scores (0–3) were not associated with lower rates of dementia. High Mediterranean diet score (6–9) HR 0.86 (0.39–1.88) nor middle scores (4–5) HR 0.99 (0.51–1.94) compared to low scores (0–3) were not associated with lower rates of AD. | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: Yes, 45% power to detect HR of 0.6 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Partial 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Fillenbaum, Kuchibhatla, Hanlon, et al., 2005 Subset of Duke Established Populations for Epidemiologic Studies of the Elderly (EPESE) Study | Geographical location: Durham, Granville, Vance, Warren, & Franklin Counties, NC Setting: Community Study design: Prospective cohort Number of participants enrolled: 616 Duration of follow up: Follow-up ranged from 3 – 10 years for incident dementia Time from risk factor assessment to final cognitive assessment: 3–4 yrs (data used from the wave prior to the diagnosis of dementia – assume meant in- person wave) | Age: Mean (SD): 73 Range: 65–105 Sex: [n (%)] Female: 382 (62%) Male: 234 (38%) Race/ethnicity: [n (%)] African-American 382 (62%) Other 234 (38%) Baseline cognitive status: Non-demented Inclusion criteria: ≥ 65 yo; participating in the Duke EPESE Study Exclusion criteria: The implication seems to be that the potential subjects were chosen to oversample for blacks and then all selected subjects in the community were taken. | Risk factor/exposure 1: Vitamins C and E Method of assessing risk factor/exposure 1: Self-report Proxy report Covariates/potential confounders adjusted for in analyses: Age Educational level Marital status Income Functional status Health services use # prescription drugs time frame of exposure to vitamins Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Informant interview?: Yes – does not actually say, but the CERAD protocol (which was used) does use an informant | 1) Follow-up rate: NR 2) Important baseline differences: Differed on age, education, health service use, prescription drugs 3) Outcome of interest #1 Vitamin E use at baseline or at wave prior to dementia diagnosis not associated with incident AD 4) Outcome of interest #2 Vitamin C use at baseline or at wave prior to dementia diagnosis not associated with incident AD | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: Can’t Tell 4) Adequate description of the cohort?: Yes. 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Can’t Tell 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Fitzpatrick, Kuller, Lopez, et al., 2009 Cardiovascular Health Study | Geographical location: Forsyth County, NC; Washington County, MD; Sacramento County, CA; Pittsburgh, PA Setting: Community Study design: Prospective cohort Number of participants enrolled: 2798 Duration of follow up: 5.4 years Time from risk factor assessment to final cognitive assessment: mean 5.4 years | Age: Mean (SD): 74.7 Sex: [n (%)] Female: 1654 (59.1%) Male: 1144 (40.9%) Race/ethnicity: [n (%)] White 2457 (87.8%) Non-white 341 (12.2%) Baseline cognitive status: Normal Non-demented Inclusion criteria: Medicare recipients ≥65 years of age in target counties. Exclusion criteria: Dementia or mild cognitive impairment | Risk factor/exposure 1: BMI at mid and late life Method of assessing risk factor/exposure 1: Self-report at midlife and Direct measurement at late life Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Baseline cognitive status cardiovascular and dementia risk factors (including history of hypertension, diabetes mellitus status, coronary heart disease, total cholesterol level, ankle-arm index, C- reactive protein level, interleukin 6 level, smoking status, kilocalories expended per week, and apolipoprotein E genotype) Method(s) of assessing cognitive status: NINCDS-ADRDA modified MMSE, Digit Symbol Substitution Test, Benton Visual Retention Test, Trails A and B, Center for Epidemiologic Studies Depression Scale, medications inventory, activities of daily living, instrumental activities of daily living, other physical function measures (gait speed, balance tests, grip strength, etc), and documentation of hospitalized medical events Informant interview?: no. except for deceased. | 1) Follow-up rate: Not clearly stated. Subjects with dementia and mild cognitive impairment excluded from population. 2) Important baseline differences: ≤.001 for age, sex, race, education, smoking status, diabetes mellitus, hypertension, ABI, CRP and IL-6 levels. 3) Outcome of interest #1 Classification resulted in 480 persons with incident dementia, 245 with Alzheimer disease (no vascular dementia), and 213 with vascular dementia (with or without Alzheimer disease). BMI measured at Midlife (age 50) adjusted HR Overall 1.0 (0.95–1.04) Underweight 1.47 (0.7–3.09 Normal- reference Overweight 1.04 (0.74–1.47) Obese 1.25 (0.74–2.11) 4) Outcome of interest #2 BMI measured at late life (age 65 or older ) adjusted HR Overall 0.95 (0.74–0.99) p=.008 Underweight 1.42 (0.74–2.70) Normal- reference Overweight 0.74 (0.52–1.05) Obese 0.58 (0.31–.96) p=.03 | Comments: Question 1 In evaluations of midlife obesity, an increased risk of dementia was found for obese (BMI _30) vs normal- weight(BMI20–25) persons, adjusted for demographics (hazard ratio [HR], 1.39; 95% confidence interval [CI], 1.03–1.87) and for cardiovascular risk factors (1.36; 0.94–1.95).The risk estimates were reversed in assessments of late-life BMI. Underweight persons (BMI _20) had an increased risk of dementia (1.62; 1.02–2.64), whereas being overweight (BMI_25–30) was not associated (0.92; 0.72–1.18) and being obese reduced the risk of dementia (0.63; 0.44–0.91) compared with those with normal BMI. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Fotuhi, Zandi, Hayden, et al., 2008 Subset of Cache County Study | Geographical location: Cache Country, UT Setting: Community Study design: Prospective cohort Number of participants enrolled: 3376 Duration of follow up: f/up 3 and 8 years. At least one f/u to get into study Time from risk factor assessment to final cognitive assessment: Ranged generally from 3 to 8 years | Age: Mean (SD): Grp 1 – 74.3 (6.6) Grp 2 – 73.9 (6.3) Grp 3 – 73.6 (5.5) Grp 4 – 73.4 (6.1) Grp 5 – 72.9 (6.1) Sex: [n (%)] Female: 1974 (58.4%) Male: 1402 (41.6%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: ≥ 65 yo; resident of Cache Country, UT Exclusion criteria: Dementia @ baseline; only one 3MS evaluation; incomplete info on medication use | Risk factor/exposure 1: nsaids Method of assessing risk factor/exposure 1: self report, probe questions, pill bottles Risk factor/exposure 2: vit E, vit C Method of assessing risk factor/exposure 2: : self report, probe questions, pill bottles Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Dm, cva, apoE status Method(s) of assessing cognitive status: change in 3MS score Informant interview?: No | 1) Follow-up rate: three waves, 63% and 37% 2) Important baseline differences: more females using vit E, vit C or nsaids, vit E and C users more likely to have E4 3) Outcome of interest #1 Users of all 3 (nsaids, vit e, vit c) had less decline than nonusers, but only significant in E4 carriers. 4) Outcome of interest #2 Users of vits e and c performed better at baseline as did users of nsaids alone, but only the combined users did better over time. | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes.
Fratiglioni, Wang, Ericsson, et al., 2000 Kungsholmen Project | Geographical location: Kungsholmen district in Stockholm, Sweden Setting: Community Study design: Prospective cohort Number of participants enrolled: 1473 Duration of follow up: 3 yrs Time from risk factor assessment to final cognitive assessment: 3 yrs | Age: Range: >75 Sex: [n (%)] Female: 338 (35%) Male: 897 (65%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Not demented, Lived at home, Good cognition (Mini Mental Status Examination [MMSE]>23) >75 yrs of age Resident of Kungsholmen Exclusion criteria: NR | Risk factor/exposure 1: social network Method of assessing risk factor/exposure 1: Self-report and Proxy report (nurse interviews) Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Baseline cognitive status Physical function (ADLs) Depression Vascular disease Method(s) of assessing cognitive status: DSM Informant interview?: Yes, only when participant was unable to answer | 1) Follow-up rate: Of the 1473s, 98 were excluded at baseline due to impaired cognition (MMSE<24) or institutionalization, and 172 refused to participate in the follow-up examination. Analytical sample = 1203. Follow up rate: 87.5% 2) Important baseline differences: In comparison with the participants, the dropouts were younger (odds ratio 0·96, p=0·017). Differences in social network characteristics not reported. 3) Outcome of interest #1 176 incident dementia cases (126 of Alzheimer’s disease and 32 vascular dementia) Adjusted RR compared with those who were married and living with someone RR(95% CI): Single and living alone 1·9 (1·2–3·1) Widowed/divorced and living alone 1·5 (0·9–2·2) Married and living alone 1·5 (0·4–6·4) Single and living with someone 1·4 (0·5–3·9) Widowed/divorced and living with someone 1·4 (0·4–4·7) 4) Outcome of interest #2 Adjusted RR compared to those who had daily to weekly contact with children and were satisfied: Contact less frequent than weekly and satisfying 1·3 (0·7–2·7) Contact less frequent than weekly and not satisfying 0·9 (0·4–2·3) Contact daily to weekly and not satisfying 2·0 (1·2–3·4) No children 1·4 (1·0–1·9) 5) Outcome of interest #3 RR compared to those who had close social ties on a daily to weekly basis with which they were satisfied: Contact less frequent than weekly and satisfying 1·1 (0·7–1·8) Contact less frequent than weekly and not satisfying 1·2 (0·7–2·0) Contact daily to weekly and not satisfying 1·4 (0·8–2·3) No friends or relatives 1·6 (1·0–2·6) All three social network variables were combined to construct a summary score. Compared to those with an extensive or moderate social network, those with a poor or limited social network were more likely to become demented (RR=1.6; 95% CI: 1·2–2·1). | Comments: Question1 Results for vascular and AD presented together though most dementia is diagnosed as AD. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Partial 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Freitag, Peila, Masaki, et al., 2006 Honolulu- Asia Aging Study (HAAS) | Geographical location: Oahu, Hawaii, USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 2505 Duration of follow up: 5.1 years of cognitive follow up. Time from risk factor assessment to final cognitive assessment: bp’s checked 3 times 1965–1974, cognitive evals done 1991, 1994, 1999 | Age: Mean at first assessment of dementia: 76.9 years Sex: Female: 0% Male: 100% Race/ethnicity: Japanese-American 100% Baseline cognitive status: Non-demented Inclusion criteria: Japanese-American Male Born between 1900 and 1919 Living on Oahu Exclusion criteria: NR | Risk factor/exposure 1: bp, (also pulse pressue, map Method of assessing risk factor/exposure 1: Direct measurement 3 times, five minutes apart, left arm while seated. Covariates/potential confounders adjusted for in analyses: age, education, apo E, antihypertensive meds, midlife alcohol, smoking and bmi, abi, hx of cad, cm or stroke at exam 4 (first cog assessment?) Method(s) of assessing cognitive status: NINCDS-ADRDA DSM CASI Informant interview?: Yes | 1) Follow-up rate: 84% and 90% of survivors at two follow up cognitive evaluations 2) Important baseline differences: higher midlife pulse pressures associated with older age, lower education, lower CASI score, higher bmi and higher sbp and dbp 3) Outcome of interest #1 “in the age adjusted model, sbp, dbp and map, and not pulse pressure, were significantly associated with incident dementia” (but not in fully adjusted model) 4) Outcome of interest #2 After admusting for confounders, the association remained significant only for sbp with a HR of 1.77 (1.1–2.84) for sbp ≥140 compared with sbp < 120. 5) Outcome of interest #3 Among those never treated for htn: (above is whole sample), all 4 bp components were correlated with incident dementia, an assoc that did not change after adjusting for cardiovasc confounders. HR 2.66 (1.51 – 4.68) for sbp ≥ 140 as compared to < 120. Only AD specific analysis reported - when the single bp component analyses were done (with only adj for age) the “results were similar for VaD and AD cases.” Also of interest: “none of the analyses were significant when we performed them on late-life instead of midlife bp components” | Comments: Analyses done for nonspecific dementia, that included 148 cases of AD. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Gallacher, Bayer, Fish, et al., 2009 Caerphilly Study | Geographical location: UK Setting: Community Study design: Prospective cohort Number of participants enrolled: 2398 in parent study; 1160 analyzed and 982 with complete covariate data Duration of follow up: Mean 17.3 (1.3) years Time from risk factor assessment to final cognitive assessment: Mean 17.3 years | Age: Range: 48–67 at enrollment; Sex: [n (%)] Female: 0, 0% Male: 1160, 100% Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Men Exclusion criteria: NR | Risk factor/exposure 1: Anxiety: 20-item trait scale of the State Trait Anxiety Inventory (STAI); dichotomized at score of 31 (≥ 31^st^ percentile) Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Educational level Marital status Alcohol consumption National Adult Reading test for cognitive function Vascular risk factors Method(s) of assessing cognitive status: 2-stage assessment; dementia using DSM, CIND using CAMCOG <83 or CAMCG decline of ≥ 10 points or unable to produce a CAMCOG despite an attempt but without functional impairment or dementia Informant interview?: No | 1) Follow-up rate: 1160/2358 with baseline anxiety scores (49%) 2) Important baseline differences: Multiple differences for those with low vs. high anxiety: social class, education, current smoker, GHQ30 score Also multiple differences between analytic sample and overall cohort. 3) Outcome of interest #1 Of total sample (1160), 69 had incident dementia and 174 CIND. OR for dementia/CIND with STAI in 31^st^ to 95^th^ percentile OR 2.19 (95% CI 1.24–3.88). Sensitivity analysis excluding men with some decline at baseline, OR 3.36 (1.61,7.01) 4) Outcome of interest #2 OR for CIND with STAI in 31^st^ to 95^th^ percentile OR 2.31 (95% CI 1.20–4.44). Sensitivity analysis excluding men with some decline at baseline, OR 3.32 (1.51,7.31) | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Can’t Tell 2) Selection minimizes baseline differences in prognostic factors?: Can’t Tell 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Partial, assessment for CIND incomplete 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: No 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Gatz, Tyas, St John, et al., 2005 Manitoba study of health and aging | Geographical location: Manitoba, Canada Setting: Community Study design: Prospective cohort Number of participants enrolled: 766 Duration of follow up: 5 years Time from risk factor assessment to final cognitive assessment: 5 years | Age: Mean (SD): 74.5 (6.0) Range: 65–96 Sex:(%) Female: 473 (61.7%) Male: 293 (38.3%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented - >77 on 3MS Inclusion criteria: Age >=65 Randomly selected from those living at home in Manitoba Fluent – english or french Exclusion criteria: Life-threatening condition Unable to complete screen due to illness or sensory deficits | Risk factor/exposure 1: Depression – Center for Epidemiological Studies Depression Questionnaire score ≥16 2. Participant reported history and duration of depression Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Method(s) of assessing cognitive status: 2 –stage screening NINCDS-ADRDA Informant interview?: No | 1) Follow-up rate: NR Around 20% were lost to follow up due to death. 2) Important baseline differences: NR 3) Outcome of interest #1 CESD>=16 OR for AD (36 cases) after 5 years f/u = 2.75 (95% CI 1.04 to 7.24) adjusted for age, sex, education Subject reported h/o depression was not associated with AD at 5 years; OR 1.50 (95% CI 0.49 to 4.63) Subject reported duration of depression was not associate with AD at 5 years; OR 1.01 (95% CI 0.88 to 1.15) | Comments: Mean education low at baseline 10.4 years (3.2) Subjects who died before f/u were older, had fewer years education and higher baseline CESD scores – could bias against an association. Analysis using logistic regression Quality assessment: For observational studies: 1) Unbiased selection of the cohort: Yes 2) Selection minimizes baseline differences in prognostic factors: Yes 3) Sample size calculated/5% difference: No 4) Adequate description of the cohort: Partial 5) Validated method for ascertaining exposure: Partial 6) Validated method for ascertaining clinical outcomes: Yes 7) Outcome assessment blind to exposure: Can’t Tell 8) Adequate follow-up period: Yes 9) Completeness of follow-up: Can’t Tell 10) Analysis controls for confounding: Yes 11) Analytic methods appropriate: No
Geda, Knopman, Mrazek, et al., 2006 Mayo Alzheimer Registry | Geographical location: Olmsted County, Minnesota Setting: Clinical Study design: Prospective cohort Number of participants enrolled: 840 Duration of follow up: 3.5 years Time from risk factor assessment to final cognitive assessment: NR | Age: Range: 50–102 Sex: [n (%)] Female: 519 (61.8) Male: 321 (38.2) Race/ethnicity: [n (%)] NR Baseline cognitive status: Normal Inclusion criteria: NR Exclusion criteria: Neurologic or psychiatic condition judged to interfere with cognitive assessment (including current depression) Psychiatric medicines that could compromise cognition | Risk factor/exposure 1: Depression; GDS (15 items) >= 6 before MCI diagnosis 2: History of depression Method of assessing risk factor/exposure 1: Self-report every 12–18 months 2: Clinical history-not specified Risk factor/exposure 2:. APOE Genotype Method of assessing risk factor/exposure 2: Direct: PCR using standard methods Covariates/potential confounders adjusted for in analyses: Age Educational level Sex Method(s) of assessing cognitive status: Clinical assessment, nuropsychological battery, MRI MCI by Petersen criteria (memory complaint, normal ADLs, normal general cognitive function, abnormal memory for age, not demented) Informant interview?: Yes | 1) Follow-up rate: NR 2) Important baseline differences: Depressed group older (mean of 84 vs. 77) and more female (68.5% vs. 60.4%) 3) Outcome of interest #1 MCI (50 cases) GDS >=6 (143 subjects) HR=2.2 (95% CI 1.2 to 4.1) Interaction between history of depression and GDS>=6 compared to referent group of no history and no current depression showed: HR = 4.5 (95% CI 1.9 to 10.9) for no h/o depression and GDS >=6 HR = 2.9 (95% CI 1.5 to 5.8) for h/o depression and GDS <6 HR = 2.6 (95% CI 1.1 to 6.3) for h/o depression and GDS >=6 Test for multiplicative interaction, p=0.008, antagonistic; additive interaction, p=0.3 Addtitional analysis showed: a non-significant increased risk for depressed men vs. women no “dose response” relationship when analyzing by depression severity (GDS scores) or duration of depressive symptoms significant interaction between APOE genotype – increasing the HR for MCI | Comments: Mean duration of f/u less for depressed cohort (2.6 vs 3.5 years) Cox Proportional Hazards Model Quality assessment: For observational studies: 1) Unbiased selection of the cohort: Yes 2) Selection minimizes baseline differences in prognostic factors: Yes 3) Sample size calculated/5% difference: No 4) Adequate description of the cohort: Partial (no race) 5) Validated method for ascertaining exposure: Partial (h/o depression not defined) 6) Validated method for ascertaining clinical outcomes: Yes 7) Outcome assessment blind to exposure: Yes for APOE; Can’t Tell for depression 8) Adequate follow-up period: Partial, depressive symptoms may be prodrome 9) Completeness of follow-up: Can’t Tell 10) Analysis controls for confounding: Partial (no race) 11) Analytic methods appropriate: Yes
Geerlings, den Heijer, Koudstaal, et al., 2008 Rotterdam Study | Geographical location: The Netherlands Setting: Community Study design: Prospective cohort Number of participants enrolled: 563 consented 486 analyzed Duration of follow up: 5.9 (1.6) years Time from risk factor assessment to final cognitive assessment: 5.9 (1.6) years | Age: Range: 60 – 90 years Sex: [n (%)] Female: 238 (49%) Male: 248 (51%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Age 60–90 Random selection stratified by age and sex Exclusion criteria: Dementia Blind Contraindications to MRI | Risk factor/exposure 1: History of Depression requiring the attention of a GP, psychologist or psychiatrist 2. Current depression defined by CES >=16 Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Baseline cognitive status Subjective memory complaint score Method(s) of assessing cognitive status: 2 stage evaluation; NINCDS-ADRDA Informant interview?: No | 1) Follow-up rate: 486/563 (86%) 2) Important baseline differences: More women in depressed group 3) Outcome of interest #1 Risk of incident AD (33 cases) H/O depression, HR 2.46 (95% CI 1.15 to 5.26) CESD >=16 at baseline, HR1.02 (95% Ci 0.40 to .64) Subgroup Analysis H/O depression with onset before age 60 vs >=60 Early onset, 7 cases of AD, HR 3.70 (1.43 to 9.58) Late onset, 5 cases of AD, HR 1.71 (0.62 to 4.74) No h/o depression, 21 cases of AD, Reference group | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort: Yes 2) Selection minimizes baseline differences in prognostic factors: Yes 3) Sample size calculated/5% difference: No 4) Adequate description of the cohort: Partial 5) Validated method for ascertaining exposure: Partial, based on self-report 6) Validated method for ascertaining clinical outcomes: Yes 7) Outcome assessment blind to exposure: Can’t Tell 8) Adequate follow-up period: Yes 9) Completeness of follow-up: Yes 10) Analysis controls for confounding: Yes 11) Analytic methods appropriate: Yes
Glynn, Beckett, Hebert, et al., 1999 | Geographical location: Boston, USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 3657 in overall cohort followed for up to 6 years Subsample 2068 age 65–81 with BP 9 years prior to cognitive baseline Duration of follow up: 6 years of cognitive assessments Time from risk factor assessment to final cognitive assessment: 6 years 9–15 years in subsample age 65–81 | Age: Mean (SD): 72.5 to 75.2 across BPgroups Sex: [n (%)] Female: 2230 (61%) Male: 1427 (39%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Not specified, but suspect many with cognitive impairment based on a mean of > 2 errors on SPMSQ Inclusion criteria: Resident of East Boston Age ≥ 65 yo Non-institutionalized. Exclusion criteria: NR | Risk factor/exposure 1: BP at baseline; SBP classified into 5 groups (130–139 referent); DBP classified into 4 groups (70–79 referent) Method of assessing risk factor/exposure 1: Direct measurement based on average of 3 measures 30 seconds apart Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Time in study Method(s) of assessing cognitive status: 9-item SPMSQ 6-item East Boston Memory Test Stratified analyses by antihypertensive med use and medical comorbidities | 1) Follow-up rate: 3657 at baseline; 2736 (75%) SPMSQ and 2679 (73%) EBMT at 3 years, 524 died in interval; 1994 (54.5%) SPMSQ and 1970 EBMT (53.9%), 631 died in interval 2) Important baseline differences: Significant differences between BP groups on multiple factors: baseline cognition, age, education, vascular risk factors 3) Outcome of interest #1 Overall, BP at baseline or 9 years earlier was not associated with 6 year change in cognition. Only those with SBP ≥ 160 9 years prior to baseline 1 of the 5 SBP groups) had a greater increase in SPMSQ errors over time | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Partial, uncertain responsiveness to change 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: No 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Gonzalez, Bowen and Fisher, 2008 Health and Retirement Study—HRS Merged with AHEAD cohort | Geographical location: United States Setting: Community Study design: Prospective cohort Number of participants enrolled: 18,465 Duration of follow up: 6 years Time from risk factor assessment to final cognitive assessment: 6 years | Age: Range: 51 to 80+ Sex: Female: 10,867 (57.2%) Male: 7,598 (42.8%) Race/ethnicity: [n (%)] White: 15,334 (87.7%) Nonwhite: 3,119 (12.3%) Baseline cognitive status: Nationally representative sample, irrespective of baseline cognitive status Inclusion criteria: Multistage probability sample, reportedly representative of the U.S. population over age 50 in 1998. Exclusion criteria: Institutionalized | Risk factor/exposure 1: Depressive symptoms Method of assessing risk factor/exposure 1: Self-report. Depressive Sxs in the week prior to interview. CES-D scale. 8-item version. Score range 0–8 Risk factor/exposure 1: Cardiovascular risk factors. Method of assessing risk factor/exposure 1: Self report. Respondents asked if a doctor ever told them they had diabetes, stroke, HTN, or CVD Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Wordlist exposure frequency Households with more than 1 respondent Method(s) of assessing cognitive status: Verbal learning and memory of a 10-word list learning task Immediate recall: immediately after having been read a list of 10 words. Delayed: after 3 minutes of interference tasks. Informant interview?: No | 1) Follow-up rate: 72.3% combined year response rate. Wave-to-wave re-interview response rates ranged from 92.1% to 87.5%. 2) Important baseline differences: NA 3) Outcome of interest #1 Depressive sxs were associated with significantly lower Immediate (−0.05; p<0.001) and Delayed (=−0.06; p<0.001) word list recall scores. 4) Outcome of interest #2 Depressive Sx: Betas and SE: Immediate recall: −0.05 (0.00), p<0.001 Delayed recall: −0.06 (0.00), p<0.001 5) Outcome of interest #3 CVD risk factors Betas and SE: Immediate recall: −0.07 (0.001), p<0.001 Delayed recall: −0.10 (0.00), p value not reported, but > 0.001 | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Graves, Rajaram, Bowen, et al., 1999 KAME Project | Geographical location: King County, Washington, USA Setting: Community Clinical – institutionalized and non institutionalized patients in the census Study design: Prospective cohort Number of participants enrolled: 1836 at baseline 1604 at 2 yr follow up Duration of follow up: 2 years Time from risk factor assessment to final cognitive assessment: Life-long exposure or since childhood. Measurement is 2 years follow up for cognition. | Age: Range: 65–95+ Sex: [n (%)] Female: 1028(56%) Male: 808 (44%) Race/ethnicity: [n (%)] Japanese origin (96%) Japanese American (1 parent only Japanese) 4% Baseline cognitive status: Non-demented Inclusion criteria: 65 y or older Living in King County, WA With Japanese Heritage; 1 or 2 parents Japanese. Exclusion criteria: Dementia Younger than 65 | Risk factor/exposure 1: Migration history, education, number of years lived in Japan before age 18 y, age at which English became main language spoken at home, language usually spoken at home currently, current facility with reading and writing Japanese. Method of assessing risk factor/exposure 1: Self-report With highly structured interview Risk factor/exposure 2: Friends growing up being mainly Japanese vs. non Japanese, or even number of both. Current friends Japanese, non Japanese or even number of both. Current religion. Diet consistent of mainly Asian food, Asiand and western equally or mainly western. Method of assessing risk factor/exposure 2: Self-report with highly structured interview. Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Baseline cognitive status f/u time Method(s) of assessing cognitive status: Other – CASI (cognitive abilities screening instrument) decline was defined as mean change – 1 SD, ie:>5.15 points loss in 2 yrs. Random measurement error inherent in CASI taken into account. Informant interview?: No | 1) Follow-up rate: 87% completed 2 year follow up. 77 died 117 refused 2^nd^ testing. 37 moved or where lost to f/u 2) Important baseline differences: NR. 3) Outcome of interest #1 CASI mean change −1 SD of −5.15 points= 144 decliners 1455 non decliners 4) Outcome of interest #2 After adjusting for baseline age, sex, baseline CASI score, education and follow up time the results are as follows: - Home language only/mostly Japanese: OR:0.45 CI 0.23–0.86, p<.01 - English Home language after 40 y : OR 0.42, CI 0.21–0.81 p<.01 - Baseline interview taken in Japanese: OR0.38, CI 0.21–0.69 p<.01 - Generation Issei (born in Japan) OR 0.28, CI 0.13–0.58 p<.01; - Kibei (born in US, Japan education) OR 0.58, CI 0.33–1, p<.05, compared to US born and educated - Any education in Japan: OR 0.44, CI: 0.27–0.73, p<.01 - Years lived in Japan 1–7 OR 0.46, CI 0.23–0.91, P<.05; - Years lived in Japan 8–15: OR0.38, CI 0.19–0.78, p<.01; - Years lived in Japan 16–18: OR 0.32, CI 0.15–0.69, p<.01, compared to 0 years - Reads/write Japanese with no difficulty: OR 0.42, CI: 0.23–0.77, p<.01; - Reads/write with difficulty OR 0.96, CI 0.62– 1.47; compared to Does not read/write Japanese -Current friends mostly Japanese: OR0.64, CI 0.44–0.93, p<.01; Past friends mostly Japanese OR 0.91, CI 0.63–1.33 5) Outcome of interest #3 - Eastern religion (Buddhist, Shinto) OR 1.34, CI 0.87–2.07 - - Eat only Asian foods OR 0.96, CI 0.62–1.49. | Comments: Question 2 Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Partial 2) Selection minimizes baseline differences in prognostic factors?: Yes. 3) Sample size calculated/5% difference?: No. 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes.
Gray, Anderson, Crane, et al., 2008 Adult Changes in Thought study (ACT) | Geographical location: Seattle, WA Setting: Clinical – Group Health Cooperative Study design: Prospective cohort Number of participants enrolled: 2969 Duration of follow up: Mean 5.5 (± 2.7) yrs Time from risk factor assessment to final cognitive assessment: Mean 5.5 (± 2.7) yrs | Age: Mean (SD): Group A 75.4 (6.2) Group B 76.1 (6.6) Group C 75.4 (6.2) Sex: [n (%)] Female: 1768 (60%) Male: 1201 (40%) Race/ethnicity: [n (%)] Caucasian 2681(90.3%) Other 288 (9.7%) Baseline cognitive status: Non-demented Inclusion criteria: Participating in Adult Changes in Thought (ACT) study; free of dementia (CASI ≥86, or scored <86 but had no evidence of dementia based on additional medical record review and standard clinical and neuropsychological evaluation for dementia) Exclusion criteria: NR | Risk factor/exposure 1: Nutritional intake of Vit C, E, or multivitamins (MVI) for at least 1 week during the previous month at baseline. Method of assessing risk factor/exposure 1: Self-report Risk factor/exposure 2: APOE Method of assessing risk factor/exposure 2: Direct measurement Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Exercise Smoking status Self-reported health Coronary heart disease Method(s) of assessing cognitive status: Screened with CASI every 2 years. If score <86, underwent dementia diagnostic eval. Relevent lab tests and brain CT performed or obtained from records. NINCDS-ADRDA DSM IV Informant interview?: No | 1) Follow-up rate: 2969/3392 (87.5%) 2) Important baseline differences: NA 3) Outcome of interest #1 Primary analysis examined whether baseline vitamin E or C use was associated with incident AD, compared with nonuse: no vitamin E, vitamin C, or MVI. Also looked at potential synergistic effect of Vitamin E and C. Results: “No difference was found in degree of association between supplement use and overall dementia or AD risk when stratified according to age.” 4) Outcome of interest #2—AD Adjusted HR’s (95% CI) for possible or probable AD. 1. No vitamins (n=106): 1.0 (referent) 2. Any Vit. E (n=89): 1.04 (.78–1.39) 3. Any Vit. C (n=105): 0.95 (.72–1.25) 4. Any MVI (n=134): 0.94 (.72–1.22) | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Partial 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes: 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Green, Rebok and Lyketsos, 2008 BLSA | Geographical location: Baltimore, USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 3481 adults interviewed at wave 1 1920 interviewed at wave 3 and 1071 interviewed at wave 4. 874 included in this analysis. Duration of follow up: 10.9 yrs. Time from risk factor assessment to final cognitive assessment: 10.9 yrs. | Age: Mean (SD): 47.3 at enrollment. Sex: [n (%)] Female: 550 (62.9%) Male: 324 (37.1) Race/ethnicity: [n (%)] AA 322 (36.8%) White 526 (60.2%) Other 26 (2.97) Baseline cognitive status: Mean MMSE 28.9 but individuals with decreased cognition not specifically excluded Inclusion criteria: Participants having cognitive scores at wave 3 and 4 Exclusion criteria: NR | Risk factor/exposure 1: Network size Method of assessing risk factor/exposure 1: Self-report Risk factor/exposure 2: Frequency of interaction Method of assessing risk factor/exposure 2: Self-report Risk factor/exposure 3: Emotional support Method of assessing risk factor/exposure 3: Self report. Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Past year household income Depressive symptomatology Lifetime alcohol use disorder, Ability to perform ADLs Cerebrovascular disease. Baseline cognitive status Method(s) of assessing cognitive status: MMSE Delayed recall Informant interview?: No | 1) Follow-up rate: 33.53% 874 out of 2607 2) Important baseline differences: Assessed participants were younger, had more education, higher income and higher MMSE scores. 3) Outcome of interest #1 After adjustment of covariates, participants with more frequent contacts at baseline exhibited greater decline in delayed recall p = 0.042. When this was controlled for health factors, p= 0.057. 4) Outcome of interest #2 After adjusting for Age Race Sex Educational level Past year household income Depressive symptomatology Lifetime alcohol use disorder, Ability to perform ADLs Cerebrovascular disease change in MMSE was not significantly affected by network size β= 0.028 (−0.037, 0.093) p= 0.403; frequency of contact β = 0.002 (− 0.073, 0.078) p= 0.950; emotional support β = −0.004 (−0.047, 0.040) p= 0.862; or composite social network β = 0.005 (−0.023, 0.033) p = 0.721 at wave 3. | Comments: Follow up rate is poor and there are significant differences between the groups that were followed and those who were lost to follow up. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: No 2) Selection minimizes baseline differences in prognostic factors?: No 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: No 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Grodstein, Skarupski, Bienias, et al., 2008 CHAP (Chicago) | Geographical location: 3 neighborhoods (Morgan Park, Beverly, & Washington Heights) in south Chicago, IL Setting: Community Study design: Prospective cohort Number of participants enrolled: 4409 Duration of follow up: From 3 to 9 years Time from risk factor assessment to final cognitive assessment: from 3 to 9 years Details on lifetime use of NSAIDS collected at Cycle 2 – concurrent with one time point of cognitive change score – also new users of NSAIDS could be identified in Cycle 2 | Age: Range: 65+ yo Sex: [n (%)] Female: 2722 (61.7%) Male: 1687 (38.3%) Race/ethnicity: [n (%)] White 1699 (38.5%) Black 2710 (61.5%) Baseline cognitive status: did not remove demented folks (or even dx dementia) Inclusion criteria: ≥65 yo; completed baseline & at least 1 f/u interview Exclusion criteria: NR | Risk factor/exposure 1: nsaids Method of assessing risk factor/exposure 1: checked pill bottles, self reported duration of use Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Interaction of time with each Cardiovascular factors Method(s) of assessing cognitive status: change in test scores Informant interview?: No | 1) Follow-up rate: 90% did 3 follow ups, 80% did all four 2) Important baseline differences: ASA users higher educ, more whites, more strokes NSAID users-more joint pain Both ASA and NSAID-higher global cognitive score 3) Outcome of interest #1 No relation of current use of ASA or NSAIDS to cog decl. 4) Outcome of interest #2 No relation to longer use of ASA. 5) Outcome of interest #3 For NSAIDS, longer use assoc. with slower cog. decl. For analysis with the lowest 10% of baseline scores out, mean cog decline of 0.009 (p=0.02) with short use; 0.013 (p-0.06) with longer use. (NSAIDS) Data not changed in this analysis with ASA. | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Partial 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Haag, Hofman, Koudstaal, et al., 2009a The Rotterdam Study | Geographical location: Rotterdam, The Netherlands Setting: Community Study design: Prospective cohort Number of participants enrolled: 6992 Duration of follow up: Mean 9.2 yrs (up to 15.3 yrs) Time from risk factor assessment to final cognitive assessment: Anytime prior to event | Age: Mean (SD): 69.4 (9.1) Sex: [n (%)] Female: 4195 (60%) Male: 2797 (40%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Age ≥55; residing in Ommoord, NE Exclusion criteria: Dementia; <6 mos medication history | Risk factor/exposure 1: statins – Simvastatin (58.7%) Pravastatin (13.5%) Atrovastatin (13%) Fluvastatin (5.7%) Cerivastatin (0.5%) Rosuvastatin (0.2%) Non-statin cholesterol lowering drugs (8.4%) of Rx Method of assessing risk factor/exposure 1: Direct measurement Other – pharmacy records Risk factor/exposure 2: Age, sex, education level, smoking Method of assessing risk factor/exposure 2: Self-report Covariates/potential confounders adjusted for in analyses: Age, Sex, use of other lipid lowering agents, education, systolic blood pressure, smoking, total serum cholesterol, BMI, DM, cardiovascular illnesses and cerebrovascular illnesses. Method(s) of assessing cognitive status: NINCDS-ADRDA Other – MMSE<26 OR Geriatric Mental State organic level >0 underwent Cambridge examination for mental disorders of the elderly. If dementia suspected, “more extensive neuropsychological testing was performed.” Incident dementia from medical records (GP and Mental Health) Informant interview?: No | 1) Follow-up rate: NR 438 people who were not exposed to statins developed AD. HR = 1.00 (REF) 28 people who were on statins developed dementia. HR= 0.57 (0.37–0.90) | Comments: Very good exposure data based on pharmacy records (but no data on adherence) Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Can’t Tell, not reported in this manuscript but sample comparable to other reports from this study that had adequate follow-up rates. 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Haag, Hofman, Koudstaal, et al., 2009b Rotterdam study | Geographical location: Ommoord, a district of Rotterdam, the Netherlands Setting: Community Study design: Prospective cohort Number of participants enrolled: 6249 Duration of follow up: Up to 13.3 years Average 8 years Time from risk factor assessment to final cognitive assessment: average 8 years | Age: Mean (SD): 68.4 Sex: [n (%)] Female: 3749 (60%) Male: 2500 (40%) Race/ethnicity: [n (%)] Caucasian 6249 (100%) Baseline cognitive status: Non-demented Inclusion criteria: All persons aged _55 years living in Ommoord, a district of Rotterdam, were invited to participate. Of 10,275 eligible persons, 7,983 (78%) signed informed consent. Of these, 7,528 (94%) were screened for dementia and 7,046 were free of dementia at baseline Exclusion criteria: dementia | Risk factor/exposure 1: antihypertensives Method of assessing risk factor/exposure 1: Other – pharmacy record Covariates/potential confounders adjusted for in analyses: Age Sex Educational level systolic and diastolic blood pressure, current smoking, total serum cholesterol, body mass index, diabetes mellitus, and cardiovascular and cerebrovascular disease. All analyses were adjusted for age, sex, and systolic and diastolic blood pressure (model I). To adjust for potential confounders (model II) included smoking, total serum cholesterol, education, body mass index, diabetes mellitus, and cardiovascular and cerebrovascular disease. Method(s) of assessing cognitive status: DSM III-R NINCDS-ADRDA Informant interview?: No | 1) Follow-up rate: 6249/7046= 88.7% 2) Important baseline differences: NR 3) Outcome of interest #1 Model II HR for AD (432 cases) Any Anti-hypertensive Never use: 1.0 <1.6 years 0.91 (.71–1.17) 1.6–5.3 years: 0.73 (.55–.96) >5.3 years 0.69 (.46–1.05) HR per year treatment: 0.94 (.90–.99) 4) Outcome of interest #2 Antihypertensive use by age: Model II HR for AD Age <75 or >75 no significant association between use of antihypertensives and AD 5) Outcome of interest #3 Model II HR for AD No differences were found between classes of antihypertensive medications and AD. | Comments: Question 1 Antihypertensive use was associated with a reduced risk of all dementia (adjusted HR per year of use 0.95; (95% CI 0.91–0.99). An 8% (−15% to −1%) risk reduction per year of use for persons ≤75 years was observed, whereas for persons >75 years this was 4% (95% CI −11% to 4%). Equivalent estimates were observed for AD. No apparent differences were observed among different types of antihypertensive drugs. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Haan, Shemanski, Jagust, et al., 1999 Cardiovascular Health Study (CHS) | Geographical location: Medicare files: Forsyth County, NC Sacramento County, CA; Washington County, MD; Pittsburgh, PA Setting: Community Other – Medicare files Study design: Prospective cohort Number of participants enrolled: Not clear-number of subjects with testing at each year is listed. 3622 subjects had 3MS at 7 year followup (listed as year 9 in Table 1); 3333 had digit symbol substitution test. Duration of follow up: 5–7 years Time from risk factor assessment to final cognitive assessment: 5 years one cohort; 7 years other cohort | Age: Range: ≥ 65 years Sex: [n (%)] Female: 57% Male: 43% Race/ethnicity: [n (%)] 85% white 5% black Baseline cognitive status: Non-demented Inclusion criteria: Residence in counties of interest; Age≥65; not institutionalized; Able to give informed consent Exclusion criteria: Age<65; not able to give informed consent. | Risk factor/exposure 1: Hypertension (Systolic Bp>158mm Hg) Method of assessing risk factor/exposure 1: Direct measurement Risk factor/exposure 2: Diabetes-presence also identified at biannual follow-up visit. All diabetes included in analysis. Method of assessing risk factor/exposure 2: Self-report and confirmed by medical record review or physician questionnaire. Risk Factor/exposure 3: APOE ɛ4 Method of assessing risk factor/exposure 3: Genotyping Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Incident stroke Method(s) of assessing cognitive status: 3MSE Digit symbol substitution test Informant interview?: No | 1) Follow-up rate: NR 2) Important baseline differences: NR 3) Outcome of interest #1 7 year change Risk: Systolic BP>158 DSS- Risk absent: −.09 Risk present: −.62 P<.0001 3MSE Risk absent: −.16 Risk present: −1.12 Increase in bp of 1 sd over mean (21.84 mmHg) was associated with a decrease of 0.96 pts in 3MS over 7 years and 0.53 points in DSS over 7 years. Legend seems to indicate both were significant at p<0.0001. 4) Outcome of interest #2 7 year change Risk Diabetes mellitus DSS- Risk absent: −.23 Risk present: −1.61 P<.0001 3MSE Risk absent: −.10 Risk present: −.71 5) Outcome of interest #3 7 year change Risk APOE ɛ4 any DSS Risk absent: −.29 Risk present: −2.00 P<.0001 3MSE Risk Absent: −.42 Risk Present: −2.94 6) Outcome of interest #4 Annual rate of change on 3MSE in subjects with and without APOEɛ4 AND with or without Diabetes. + APOEɛ4 and + DM: −.39 + APOEɛ4 and − DM: −.70 −APOEɛ4 and +DM: −.46 −APOEɛ4 and −DM: −.23 P<.001 for interaction (f/u year x risk factor x APOEɛ4) Ratio of annual decline with APOEɛ4 + APOEɛ4 and + DM: 1.67 + APOEɛ4 and − DM: 3.01 −APOEɛ4 and +DM: 1.99 −APOEɛ4 and −DM: 1.00 All values adjusted for age, sex, education. | Comments: Data reported as change over 7 years of follow-up, but second cohort recruited at year 5- so they did not include this cohort in analysis- The first cohort was 95% white. Diabetes assessed at biannual f/u visits and lumped into analysis. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Can’t Tell 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Hakansson, Rovio, Helkala, et al., 2009 CAIDE study | Geographical location: Kuopio and Joensuu regions in eastern Finland Setting: Community Study design: [Prospective cohort Number of participants enrolled: 1449 Duration of follow up: Average 21 years Time from risk factor assessment to final cognitive assessment: Average 21 years | Age: Mean (SD): 50.4 (4.9) Range: 65–79 Sex: [n (%)] NR Race/ethnicity: [n (%) Caucasian Baseline cognitive status: Non-demented Inclusion criteria: The participants of the CAIDE study comprised a random sample of 2000 survivors from four separate population samples, originally investigated in 1972, 1977, 1982, or 1987. Age at original enrollment 30–59. Exclusion criteria: NR | Risk factor/exposure 1: marital status (married/cohabiting, single, divorced, or widowed) measured at mid-life and follow-up. Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Baseline cognitive status BMI APO E Systolic BP Region of residence Smoking Occupation Physical activity at work Depression at mid-life Method(s) of assessing cognitive status: If MMSE score <24 then NINCDS-ADRDA DSM-IV Informant interview?: No | 1) Follow-up rate: 1449/2000= 72% 2) Important baseline differences: % participated in follow-up Age, % women, education, occupation physical activity, % smokers midlife, % office workers 3) Outcome of interest #1 Risk of AD (44/1216) Status at mid-life Without partner 2.06 (0.9–4.7) Widowed 2.52 (0.8–7.7) Single/divorced 1.78 (0.7–4.9) 4) Outcome of interest #2 Risk of Cognitive Impairment (131/1303) Status at mid-life Without partner 2.09 (1.3–3.4) Widowed 2.76 (1.5–5.2) Single/divorced 1.56 (0.9–2.8) 5) Outcome of interest #3 Risk of MCI (78/1250) Status at mid-life Without partner 2.14 (1.2–3.8) Widowed 3.30 (1.6–6.9) Single/divorced 1.50 (0.7–3.4) With cohabiting apolipoprotein E e4 non-carriers as reference, the odds ratio for apolipoprotein E e4 carriers who had been widowed or divorced both in mid-life and later life was OR 25.55 (5.7 – 114.5, P<0.001) OR for APOE e4 carriers who were widowed or divorced both at baseline and follow-up was considerably lower with mild cognitive impairment as outcome (OR 4.68, 1.65 to 13.3) OR for those who were widowed or divorced after mid-life for mild cognitive impairment (2.66, 1.1 to 6.2) and for Alzheimer’s disease (5.0, 1.4 to 17.5) were generally lower than those widowed or divorced at mid-life. | Comments: Question 1 and 2 – yes cat Dx No cognitive screening at enrollment. MMSE done at end of study. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Hayden, Zandi, Khachaturian, et al., 2007 Cache County Study | Geographical location: Cache County, UT Setting: Community Study design: Prospective cohort Number of participants enrolled: 3383 Duration of follow up At least one follow up, baseline 95–96, first f/u 98–99, second 02–03 Ranged from 3 – 8 years Time from risk factor assessment to final cognitive assessment: ranged from 3 to 8 years approximately | Age: Mean (SD): NSAID users 73.7 (6.2) Non-NSAID 74.2 (6.5) Sex: [n (%)] Female: 1978 (58.4%) Male: 1405 (41,6%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: ≥ 65 yo; pts contributed multiple time points for longitudinal analysis Exclusion criteria: Dementia @ baseline; pt provided a 3MS score at only one time point; pt provided incomplete info on NSAID use | Risk factor/exposure 1: NSAID use Method of assessing risk factor/exposure 1: self report, probe questions, pill bottles Covariates/potential confounders adjusted for in analyses: Age Sex, education, apoE, dm, cva, time followed up, quadratic term for time [I would not consider these to be covariates] okay Method(s) of assessing cognitive status: Change on the 3MS Informant interview?: No | 1) Follow-up rate: 97.3% first f/u exam 66.0% second f/u exam 2) Important baseline differences: nsaid users more likely female, htn, high chol. sl higher 3ms scores (<half a point) 3) Outcome of interest #1 No real difference with longer term users (started pre 65 yo) who have no E4. 4) Outcome of interest #2 E4 protective with earlier start nsaids. 5) Outcome of interest #3 Later onset of use(after 65 yo), those with E4 had higher scores at baseline but same change over time. 6) Outcome of Interest #4 No E4, late start, more decline | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Can’t Tell
Hebert, Scherr, Bennett, et al., 2004 CHAP | Geographical location: Chicago, USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 6158 Duration of follow up: baseline with up to six years follow up Time from risk factor assessment to final cognitive assessment: meds checked at baseline, bp checked every time? Cognition checked every time | Age: Mean (SD): 74 (6.4) Sex: Female: 62% Male: 38% Race/ethnicity: African American 62% White 38% Baseline cognitive status: can’t tell from here, but this is the Chicago biracial study and I don’t believe they eliminated the cognitively impaired. Baseline mmse 26.3 (4.4) Inclusion criteria: Age ≥ 65 years Live in a particular geographically defined community Exclusion criteria: NR | Risk factor/exposure 1: htn/bp Method of assessing risk factor/exposure 1: Direct measurement two sitting blood pressures done each visit, mean used. Risk factor/exposure 2: antihypertensives Method of assessing risk factor/exposure 2: Self-report of meds taken within the last two weeks done at baseline visit. Implies that pill bottles were checked also. Covariates/potential confounders adjusted for in analyses: Age, Race, Sex, Educational level, either systolic or diastolic bp (whichever wasn’t examined, I think) Method(s) of assessing cognitive status: change in summary cognitive score Informant interview?: No | 1) Follow-up rate: 64% had all three visits, 36% had two visits 2) Important baseline differences: cognitive change and bp both treated as continuous variables 3) Outcome of interest #1 Outcome was predicted annual change in global outcome score over a 6 year interval for 1 mmHg increase in bp. Neither sbp nor dbp were related to cognitive change. Sbp −0.0001 (−0.0003 to 0.00001) Dbp −0.00002 (−0.00036 to 0.00032) 4) Outcome of interest #2 dbp entered as a quadratic term is said to be significant in a curvilinear fashion such that 75mmHg has a minimum decline. 5) Outcome of interest #3 “None of the indicators for medications (general antihypertensives or type of antihypertensive) substantially altered the result.” | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Partial 5) Validated method for ascertaining exposure?: Partial 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Hee Kang, Cook, Manson, et al., 2007 Women’s Health Study | Geographical location: 11 US locations Setting: Community Study design: RCT Test intervention Asa 100mg & vitamin E 600 IU on alternate days Comparator intervention(s) placebo Number of participants enrolled: 6377 Duration of follow up: For cognition follow-up was about 4 yrs (3 time pts) 9.6 years Time from risk factor assessment to final cognitive assessment: first cog assessment 5.6 yrs after randomization, then q2yrs. | Age: Mean (SD): 71.8 –71.9 Range: 70 – 81?? Sex: [n (%)] Female: 6377 (100%) Male: 0 (0%) Race/ethnicity: [n (%)] White > 6058 (> 95%) Baseline cognitive status: Assumed Normal Inclusion criteria: Participating in the Women’s Health Study; age 65 or older; providing information on NSAID and potential confounders in biennial questionnaires Exclusion criteria: No hx of CHD, CVD, CA, or other major chronic illnesses, no current use of study medications or hx of side effects from study meds | Risk factor/exposure 1: RCT 100 mg asa Method of assessing risk factor/exposure 1: RCT Covariates/potential confounders adjusted for in analyses: Age baseline score, perceived change in memory, cigarettes, education, etoh, bmi, physical activity, hrt, dm, htn, hyperchol, depression, cardiovasc dz. Method(s) of assessing cognitive status: Change over time on various cognitive measures Informant interview?: No | 1) Follow-up rate: 79.5% all cognitive assessment, 80% all assessments, 79% placebo 2) Important baseline differences: none 3) Outcome of interest #1 No differences were observed in mean change in cognitive performance by treatment assignment for cognitive outcome. | Comments: None Quality assessment: For RCTs: 1) Baseline comparability?: yes 2) Valid AD/cognitive outcomes assessment?: Yes 3) Subjects/providers blind?: Yes 4) Outcome assessors blind?: Yes 5) Incomplete data adequately addressed?: Yes 6) Differential dropout rate < 10%?: Yes 7) Overall dropout rate < 30%?: Yes 8) Conflict of interest reported and insignificant?: Yes 9) Randomization adequate?: Yes 10) Allocation concealment adequate?: Yes
Hee Kang and Grodstein, 2003 Nurses’ Health Cohort | Geographical location: 11 US States Setting: Community Study design: Prospective cohort Number of participants enrolled: 16,128 Duration of follow up: exposure 1980 and q2yrs until 1998, cognition baseline and 2 years later Time from risk factor assessment to final cognitive assessment: f/up cog testing 2 yrs after baseline which was 1995–2001 | Age: Range: 70 – 81 yo Sex: [n (%)] Female: 16,128 (100%) Male: 0 (0%) Race/ethnicity: NR Baseline cognitive status: Used cohort from ongoing study, didn’t give categorical dx Inclusion criteria: Had answered the most recent f/u questionnaire; were free of diagnosed stroke; had complete information on NSAID and aspirin use Exclusion criteria: diagnosed stroke; otherwise it looks like they took everyone over 70 | Risk factor/exposure 1: nsaids/asa Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Categorical value for each test, hx dm, hx heart disease, vit E, hrt, menopause age, bmi, cigarettes, alcohol, mental health index, energy fatigue index Method(s) of assessing cognitive status: decline in testing scores Informant interview?: No | 1) Follow-up rate: 93% did baseline. Of those 90% did follow up. 2) Important baseline differences: asa and nsaid users: sl less educ, poorer health, more htn, dm, cad, more use of other meds incl antidepressants, vit E, hrt nsaid users but not asa users more likely to be obese. 3) Outcome of interest #1 many analyses and done individually for each test but over all: RR of global score decline for use of nsaids 3 years before testing: 0.95 (0.70–1.29) | Comments: Findings stated more strongly by authors in the abstract Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Partial, self-report 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Helmer, Damon, Letenneur, et al., 1999 PAQUID | Geographical location: Southwestern France Setting: Community Study design: Prospective cohort Number of participants enrolled: 5554 in cohort, 3777 (68%) agreed to participate. Duration of follow up: 4.3 yrs (SD 1.4) Time from risk factor assessment to final cognitive assessment: 4.3 yrs (SD 1.4) | Age: Mean (SD): NR 1822 older than 74 yrs at baseline. Sex: Female: 2133 (58%) Male: 1541 (42%) Race/ethnicity: NR Baseline cognitive status: Non-demented Inclusion criteria: Living at home in Southwestern France, age 65 yrs or older, Exclusion criteria: NR | Risk factor/exposure 1: Marital Status Method of assessing risk factor/exposure 1: Self-report 1) Married or cohabitant (n=2106) 2) Never married (179) 3) Widowed (n=1287) 4) Divorced or separated (n=103) 215 initially married who became widowed during the f/u period were considered married until the death of their spouses, and then considered widowed. Covariates/potential confounders adjusted for in analyses: Number of people in the social network. Satisfaction with work, living alone, number of leisure activities. Baseline CED-D score. Education and wine consumption. Stratified for sex. Cox model with delayed entry taking age at the time scale. Method(s) of assessing cognitive status: Home interviews. First, patients with suspected dementia were diagnosed using DSM IIIR criteria. Then seen by a senior neurologist who confirmed the diagnoses and applied NINCDS-ADRDA criteria. Informant interview?: No | 1) Follow-up rate: 3675 nondemented participants: 794 (21.6%) lost to followup (365 died, 12 lost to f/u, 417 refused f/u).b Follow-up rate: 2881/3675 = 78.4% 2) Important baseline differences: NA 3) Outcome of interest #1--AD 190 incident cases of dementia, 140 of which were AD and 50 “other.” 4) Outcome of interest #2— Association between marital status and AD A) Reference: [underlined: Married] (n=44) B) [underlined: Widowed] (n=74): RR 0.82 (95% CI: 0.46–1.44), p=0.487 C) [underlined: Never married] (n=18): RR 2.31 (95% CI: 1.14–4.68), p0.02 D) [underlined: Divorced] (n=4); RR 0.93 (95% CI: 0.26–3.31), p=0.917 5) Outcome of interest #3 Authors’ conclusion: “Our results…confirm that never-married individuals have a significantly higher risk of dementia or AD than married ones—a twofold increase for the risk of AD.” | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Ho, Niti, Yap, et al., 2008 Singapore Longitudinal Ageing Studies | Geographical location: South East Singapore Setting: Community Study design: Prospective cohort Number of participants enrolled: 1352 Duration of follow up: 1–2 yrs (mean 1.4 yrs – 0.5SD) Time from risk factor assessment to final cognitive assessment: 1–2 years with mean 1.4 years and median 1.5 years. | Age: Mean (SD): Group A = 64.6 (6.9) Group B = 66.2 (6.9) Sex: [n (%)] Female: 896 (66%) Male: 456 (34%) Race/ethnicity: [n (%)] Chinese Baseline cognitive status: Normal Defined by MMSE score ≥ 24 Inclusion criteria: Chinese older adults without cognitive impairment (MMSE <24) and without cardio-vascular disease and stroke; not mentally, physically, or functionally incapacitated Exclusion criteria: MMSE score<24 No stroke or cardiovascular disease | Risk factor/exposure 1: metabolic syndrome (international diabetic federation criteria) Method of assessing risk factor/exposure 1: Direct measurement Risk factor/exposure 2: metabolic syndrome Method of assessing risk factor/exposure 2: Direct measurement waist circumference >90 cm or 80cm Chinese men, women; plus any 2 of following 1. systolic bp>130, diastolic >85. 2. Elevated fasting glucose >5.6mmol/L or on diabetes drug; 3. Elevated triglycerides >1.7mmol/L or on lipid lowering drug; low HDL <0.9mmol/L in men and <1.1mmol/L women or lipid lowering agent. Covariates/potential confounders adjusted for in analyses: Age Sex Educational level (> or <6 years) Baseline cognitive status APOE Depression Current alcohol smoking Leisure activities (physical, social or productive) Method(s) of assessing cognitive status: MMSE ≥24 Informant interview?: No | 1) Follow-up rate: 2611 at baseline; 1674 reinterviewed (64%); selected 1357 cognitively unimpaired- 1352 with complete baseline and followup data 2) Important baseline differences: Subjects lost to followup more likely men and had lower MMSE scores. Of people included- Metabolic syndrome more likely to be older, female, have less than 6 yrs education, have low leisure activities; and low baseline MMSE 3) Outcome of interest #1 MMSE 2 pt decline Metabolic Syndrome more likely to have 2 pt decline MMSE 14 vs 19.9% p<.008 (OR for Metabolic syndrome 1.42 (1.10–1.98) p<0.008)- adjusted for age, gender, education, smoking, alcohol; depression, apoe4 status, level leisure activities, baseline MMSE and length of f/u 4) Outcome of interest #2 MMSE 2 point decline- adjusted for HTN OR 1.01 (0.7–1.45) | Comments: Described as prospective cohort study, but population selected from individuals who have completed baseline and f/u assessment- only 64% of population completed both assessments. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Partial 2) Selection minimizes baseline differences in prognostic factors?: Yes. 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes? Partial 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Partial 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes.
Ho, Woo, Sham, et al., 2001 | Geographical location: Hong Kong Setting: Community Study design: Prospective cohort Number of participants enrolled: 2032 initial cohort. Of these, 1200 selected by stratified random sampling. Duration of follow up: 3 years Time from risk factor assessment to final cognitive assessment: 3 years | Age: Range: 70 to 90+ Sex: Female: 469 (47.5%) Male: 519 (52.5%) Race/ethnicity: NR Baseline cognitive status: Non-demented No cognitive impairment Inclusion criteria: Elderly subjects ≥30 yrs identified by stratified (by age) disproportional random sampling among Old Age Allowance Scheme, which covers 90% of the Hong Kong elderly population. Exclusion criteria: Cognitive impairment or dementia at baseline | Risk factor/exposure 1: Sociodemographic and health factors Method of assessing risk factor/exposure 1: Self-report Multiple risk factors assessed, including: 1) Education (no formal education vs. formal education) 2) Exercise (no vs. yes) Minimal details provided. Covariates/potential confounders adjusted for in analyses: Sex only Method(s) of assessing cognitive status: Orientation part of CAPE as screening test. 12 CAPE questions asked. CI defined as scoring ≤ 7 points on the CAPE. Informant interview?: No | 1) Follow-up rate: 988 of the 1200 (83.2%). 996 were alive at f/u. 2) Important baseline differences: NA 3) Outcome of interest #1— Education No formal education vs. formal education: OR 3.2 (95% CI: 1.8, 5.5) 4) Outcome of interest #2— Exercise No vs. yes: OR 2.1 (95% CI: 1.3, 3.3) | Comments: Few details provided about risk factor assessment. Many independent variables included in the analysis were not reported. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: Can’t Tell 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Can’t Tell 6) Validated method for ascertaining clinical outcomes?: Yes (CAPE) 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Partial (sex only) 11) Analytic methods appropriate?: Yes
Holtzman, Rebok, Saczynski, et al., 2004 Epidemiologic Catchment Area (ECA) Survey, Baltimore site | Geographical location: Baltimore Setting: Community Study design: Prospective cohort Number of participants enrolled: 4238 enrolled in wave 1, however, only 881 met inclusion criteria for age and MMSE cut off. Duration of follow up: 12.4 years. Time from risk factor assessment to final cognitive assessment: 12.4 years | Age: Range: ≥ 50 years Sex: Both genders participated; statistics NR Race/ethnicity: White and non-white; statistics NR Baseline cognitive status: MMSE ≥28 Inclusion criteria: Age ≥ 50 MMSE ≥ 28 Exclusion criteria: None | Risk factor/exposure 1: Social network Method of assessing risk factor/exposure 1: Self-report Risk factor/exposure 2: Emotional support Method of assessing risk factor/exposure 2: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Baseline MMSE score Δ physical activity Δ dysphoria Lifetime presence of alcohol disorder CVD status at Wave 3 Method(s) of assessing cognitive status: MMSE Informant interview?: No | 1) Follow-up rate: 40.18 % 881 eligible, 440 lost to follow up, 107 had missing data. 2) Important baseline differences: Those who were in the analysis were younger, had higher MMSE scores, had more education and more likely to be female that those who were excluded. 3) Outcome of interest #1 After controlling for Δ physical disability and Δ dysphoria, MMSE at baseline, lifetime presence of alcohol disorder and CVD status as of Wave 3, age,, gender, and race and educationsal level, there was a linear effect of the baseline network size on the change in MMSE scores. B= 0.18 SE= .06 β = .14 p <0.01 Effect size = 0.06 P= 0.006 The variance explained by network size was very small. For example, age explained 3.2 times the variance as social network. 4) Outcome of interest #2 After controlling for Δ physical disability and Δ dysphoria, MMSE at baseline, lifetime presence of alcohol disorder and CVD status as of Wave 3, age,, gender, and race there was a significant independent effect of education on the maintenance of cognitive function. B= 0.21; SE= .05; β =21; p<0.0005 | Comments: The major threat to the validity of the article is the large amount of missing data and loss to follow up. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: No 2) Selection minimizes baseline differences in prognostic factors?: No 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes. 5) Validated method for ascertaining exposure?: No. 6) Validated method for ascertaining clinical outcomes?: Yes- though minor changes were made to the MMSE 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: No 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Huang, Zandi, Tucker, et al., 2005 Cardiovascular Health Study (CHS) | Geographical location: 4 US communities Forsyth County, NC Washington, County, MD Sacramento, CA Pittsburgh, PA Setting: Community Study design: Prospective cohort Number of participants enrolled: 2233 Duration of follow up: Est 9 yr Time from risk factor assessment to final cognitive assessment: 9 yr | Age: Mean (SD): est 71.8 Sex: [n (%)] Female: 1306 (58.5%) Male: 927 (41.5%) Race/ethnicity: White: 2166 (96.99%) Other: 67 (3.0%) Baseline cognitive status: Non-demented Inclusion criteria: ≥65 yr in 1989/90 Drawn from Medicare eligibility lists in 4 communities Had MRI as part of CHS study Exclusion criteria: NR | Risk factor/exposure 1: fatty fish Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level APOE Total energy BMI Study site income Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Informant interview?: No (informant interview only done for those who refused in-person assessment, were deceased or could not come to clinic for in- person interview) | 1) Follow-up rate: difficult to tell –required that had both nutrition data and MRI to be in analyses 2) Important baseline differences: Individuals who ate more lean, fried fish were more likely to be male, less likely to be white, and more likely to be at NC site. Those who ate more fatty fish were more likely to be male and more likely to be at NC site. 3) Outcome of interest #1 Intake of fried fish not assoc with risk of AD 0.25–2 serv/wk: HR−0.97 (0.67–1.4) ≥2 serv/wk: HR −0.95 (0.60–1.52) 4) Outcome of interest #2 Intake of tuna and other fish not assoc with risk of AD 0.25–2 serv/wk: HR −0.85 (0.54–1.33) 2–4 serv/wk: HR−0.72(0.44–1.17) >4 serv/wk: HR −0.69 (0.91–1.22) | Comments: Question 1 Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Partial 2) Selection minimizes baseline differences in prognostic factors?: Partial 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Partial 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Can’t Tell 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Hughes, Andel, Small, et al., 2009 Swedish Twin Study – HARMONY study | Geographical location: locations throughout Sweden Setting: Other –Twin Registry Study design: Prospective cohort Number of participants enrolled: 3779 (in models with covariate adjustment N = 3217) Duration of follow up: 31.47 yrs (0.91) Time from risk factor assessment to final cognitive assessment: 31.47 yrs (0.91) | Age: Mean (SD): Baseline: 48.33 (5.14) Follow-up: 79.81 (5.09) Sex: [n (%)] Female: 2346 (62.08) Male: 1433 37.92) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Members of the Swedish Twin Registry born between 1886 and 1925 who completed questionnaire in 1967. Age > 65 years at time of cognitive evaluation for dementia Exclusion criteria: NR | Risk factor/exposure 1: fruit and vegetable consumption (1 question) Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Smoking Alcohol use Exercise BMI Angina Marital status Total food intake Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Informant interview?: No | 1) Follow-up rate: 3779 of 5588 survivors participated (68%). Of these 3318 of 3779 had covariates collected. 2) Important baseline differences: NR by exposure status 3) Outcome of interest #1 Medium or great fruit and vegetable intake in mid-life associated with reduced risk of AD (OR 0.60; 95% CI: 0.41–0.86) 4) Outcome of interest #2 Medium or great fruit and vegetable intake in mid-life associated with reduced risk of AD in women (OR=0.47; CI: 0.31–0.73) but not men. Interaction significant (OR=0.45; CI: 0.21–0.98) 5) Outcome of interest #3 Significant interaction (OR=0.44; CI: 0.21–0.95) also identified where those with angina and medium/great fruit and vegetable intake had lower risk of AD (OR=0.32; CI: 0.16–0.65). No significant association observed in those without angina. | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: Can’t Tell 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: No 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Partial 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Hughes, Borenstein, Schofield, et al., 2009 KAME | Geographical location: King County, WA Setting: Community Study design: Prospective cohort Number of participants enrolled: 1478 Duration of follow up: Mean 7.8 years; SD 0.3 Time from risk factor assessment to final cognitive assessment: 7 to 9 years | Age: Mean (SD): 71.8 Sex: [n (%)] Female: 55.3 Male: 44.7 Race/ethnicity: [n (%)] 100% Japanese Baseline cognitive status: Non-demented Inclusion criteria: a population-based prospective study of community- and institution-dwelling Japanese Americans 65 years and older living in King County, WA. Exclusion criteria: none | Risk factor/exposure 1: BMI Method of assessing risk factor/exposure 1: Direct measurement Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level alcohol, smoking, hypertension, hypercholesterolemia, diabetes, angina pectoris, stroke, TIA, physical activity and APOE genotype. Method(s) of assessing cognitive status: CASI ≤86 triggers evaluation NINCDS-ADRDA DSM IV Informant interview?: Yes | 1) Follow-up rate: 1478/1836 = 80.5% 2) Important baseline differences: Female sex, alcohol, smoking, hypertension, hypercholesterolemia, diabetes mellitus 3) Outcome of interest #1 129 incident dementia cases, 71 incident AD cases, and 22 incident VaD cases Baseline BMI Model 4 (fully adjusted) HR 0.68 (0.31–1.51) 43/971 cases BMI Change Model 4 (fully adjusted) HR 0.21 (0.06–0.80) 43/971 4) Outcome of interest #2 Higher baseline BMI was significantly associated with a reduced risk of AD (HR= 0.56, (0.33–0.97)) in the fully adjusted model. 5) Outcome of interest #3 Slower rate of decline in BMI was associated with a reduced risk of dementia (HR 0.37, 0.14–0.98), with the association stronger for those who were overweight or obese (HR 0.18, 0.05–0.58) compared to normal or underweight (HR 1.00, 0.18–5.66) at baseline. | Comments: Question 1 Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Insel, Palmer, Stroup- Benham, et al., 2005 Hispanic Established Population for Epidemiologic Study of the Elderly | Geographical location: Texas, New Mexico, Colorado, Arizona, California Setting: Community Study design: Prospective cohort Number of participants enrolled: 3050 at baseline. Duration of follow up: 7 years Time from risk factor assessment to final cognitive assessment: 7 years | Normotensives (n=1138) Age: Mean (SD): 73.3 (7.2) Sex: NR Hypertensives (n=1721) Age: Mean (SD): 72.8 (6.8) Sex: NR Race/ethnicity: Mexican American population Baseline cognitive status: No exclusion for cognitive status reported. Inclusion criteria: Area probability sampling design of counties with a high proportion of Mexican Americans in 5 US states. Mexican American, ≥65 yrs Exclusion criteria: NR | Risk factor/exposure 1: Blood pressure. Method of assessing risk factor/exposure 1: Direct measurement of SBP and DBP. Baseline HTN status defined as both self- reported HTN and SBP ≥ 140. SBP and MMSE data analyzed with a latent growth curve model. The beta parameter indicates the constant rate of change per unit of time. Method of assessing risk factor/exposure: Self report for: Education, self- reported diabetes, HTN, anti-HTN medication, physical activity, tobacco use. Covariates/potential confounders adjusted for in analyses: Age BMI Sex Income Educational level Baseline MMSE score Baseline CESD score Physical activity Lifestyle factors Diabetes Stroke Cardiovascular disease Method(s) of assessing cognitive status: MMSE assessed 4 times over 7 years. Used as screen for CI. Informant interview?: No | 1) Follow-up rate: 3050 at baseline, with 2579 (84.6%) or 2859 (inconsistent reporting in the paper) with blood pressure readings at baseline and 1460 (56.6%) BP readings at 7 year f/u. 2) Important baseline differences: NA 3) Outcome of interest #1: Numerous RF’s (education, diabetes, stroke, depression, BMI, antihypertensives, smoking, physical activity) parameters reported, stratified by normotensive vs. HTN. Analysis: Regression analysis with latent growth curve models by baseline HTN status: unstandardized regression coefficients reported. Beta coefficients and SE reported below. *=p<.05, **=p<.01, ***=p<.001 [underlined: Normotensives] Education: .03 (.01)* Diabetes: .24 (.14) Depression: −.02 (.00)** BMI: 0 (.01) Anti-HTN 2: .18 (.41) Anti-HTN 3: .01 (.36) Anti-HTN 4: .81 (.34) Smoking: .02 (.11) Physical activity: .004 (.00)*** [underlined: Hypertensives] Education: .4 (.01)*** Diabetes: −.48 (.01)*** Depression: .01 (.00)** BMI: .03 (.01)*** Anti-HTN 2: −.38 (.19)* Anti-HTN 3: −.04 (.22) Anti-HTN 4: .46 (.30) Smoking: −.01 (.09) Physical activity: 0 (.00) 4) Outcome of interest #2—SBP Authors’ conclusion: “This investigation found that baseline SBP and MMSE did not predict the rate of change of MMSE over 7 years for either normotensive or hypertensive participants.” 5) Outcome of interest #3—DBP “Because DBP did not vary greatly in either group, this was not modeled and was not included in the analysis.” | Comments: Outcome is slope of change in MMSE over time. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Partial 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Partial 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
In’t Veld, Ruitenberg, Hofman, et al., 2001 Rotterdam Study | Geographical location: Rotterdam, The Netherlands Setting: Community Study design: Prospective cohort Number of participants enrolled: 6416 Duration of follow up: Mean =2.2 years Time from risk factor assessment to final cognitive assessment: Mean = 2.2 years | Age: Range: ≥ 55 years at baseline Sex: Both genders included Race/ethnicity: NR Baseline cognitive status: Non-demented Inclusion criteria: Age >=55 y.o Living in Ommoord suburb of Rotterdam for >= 1 year Exclusion criteria: Dementia | Risk factor/exposure 1: Anti-hypertensive medication Method of assessing risk factor/exposure 1: Self-report Direct measurement- medication bottles 21.1% used 1 anti-HTN medication; 8.5% two and 1.7% three or more medications. b-blocker 14.6%; diuretics 15.3%; ACE inhibitor 5.7%; other 1.9% Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Baseline cognitive status DBP and SBP H/O stroke, DM or PAD BMI Tobacco use Independent vs home for the elderly Method(s) of assessing cognitive status: NINCDS-ADRDA DSM 2- stage exam; secondary evaluation triggered by MMSE < 26 or Geriatric Mental State schedule >0. Of those who were not re-examined or who died, cognitive function assessed by close informants and general practitioners. Informant interview? Yes, for those in second stage of dementia screening, CAMDEX included informant interview. Also of those not directly reexamined (dead or not), some had informants. | 1) Follow-up rate: 5,571/6416 had f/u (87%) 2) Important baseline differences: Anti-HTN medication users were: older and had higher BMI, and more likely to be female, smoke, have DM, PAD or h/o stroke 3) Outcome of interest #1 Incident dementia =118 (70 in untreated and 48 in treated groups); of these, AD=82 Any anti-HTN medication; HR for AD = 0.77 (95% CI 0.49–1.24) HR or all dementias = 0.67 (95% CI 0.45 – 1.00) Sensitivity analyses: 1) Excluding untreated subjects w/SBP < 160 and DBP < 95; any anti- HTN use, HR for AD=0.99 (0.47 – 2.12); HR for total dementia 0.67 (0.35 – 1.32) 2) Gender: any anti-HTN use, HR for total dementia, men HR 0.52 (0.22–1.20); women HR 0.93 (0.59–1.46) | Comments: About 5% of participants lived in homes for the elderly Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Partial 7) Outcome assessment blind to exposure?: No 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Irie, Fitzpatrick, Lopez, et al., 2008 Cardiovascular Health Study (CHS) | Geographical location: Pittsburgh, PA, Forsyth County, NC, Washington county, MD, Sacramento county, CA Setting: Community Study design: Prospective cohort Number of participants enrolled: 2547 Duration of follow up: Up to 10 years Mean 5.4 years Time from risk factor assessment to final cognitive assessment: Diabetes mellitus assessed annually. | Age: Mean (SD): 74 at first examination 80.1 (exit) Sex: [n (%)] Female: 59% Male: 41% Race/ethnicity: [n (%)] 91.3% white 8.7% AA Baseline cognitive status: Non-demented Inclusion criteria: Random selection from Medicare eligibility lists in 4 counties. Non-demented on MMSE Exclusion criteria: Mild cognitive impairment and dementia | Risk factor/exposure 1: APOE genotype 602 with APOEɛ4 Method of assessing risk factor/exposure 1: Direct measurement Risk factor/exposure 2: Diabetes mellitus 320 diabetes (12.6%) Method of assessing risk factor/exposure 2: Direct measurement Medication use. Covariates/potential confounders adjusted for in analyses: Model 1: Age Race Educational level Model 2: age, race, education, HTN, total cholesterol, smoking, alcohol, BMI, depression status, ankle-brachial index, stroke. Method(s) of assessing cognitive status: NINCDS-ADRDA 3MSE DSS Informant interview?: Yes | 1) Follow-up rate: Uncertain as 5888 were recruited but only 2547 included in this analysis. Further details not available. 2) Important baseline differences: Those with DM had higher systolic Bp, total cholesterol, BMI, lower ankle-brachial index 3) Outcome of interest #1 Compared to those without DM or APOEɛ4: Model 1 (see covariates) Incident AD DM only 1.45 (0.89–2.37) APOEɛ4 only 2.61 (1.933.54) Both 4.53 (2.47–8.30) Model 2 (see covariates) DM only 1.62 (0.98–2.67) APOEɛ4 only 2.50 (1.84–3.40) Both 4.99 (2.70–9.20) | Comments: The authors conclude that having both DM and APOEɛ4 increases risk to a greater extent than simple additive contributions. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: Can’t Tell 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: No 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Can’t Tell. 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Irie, Masaki, Petrovitch, et al., 2008 Honolulu-Asia Aging Study (HAAS) | Geographical location: Oahu, Hawaii Setting: Community Study design: Prospective cohort Number of participants enrolled: 2350 Duration of follow up: Approximately 6 years Time from risk factor assessment to final cognitive assessment: NR | Age: Range: 71 – 90 Sex: Male: 100% Race/ethnicity: [n (%)] Japanese-American Baseline cognitive status: Non-demented Inclusion criteria: Born between 1900 and 1919 Living on Oahu, Hawaii Complete information on depression symptoms and APOE genotypes Exclusion criteria: Dementia Clinical dementia rating score of>=0.5 or Cognitive abilities sreening instrument score of <82 Died before first f/u exam or did not attend f/u examinations | Risk factor/exposure 1: Current depressive symptoms using 11-item CESD, (range 0–33), score >=9 Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Educational level Awareness of memory problem and cardiovascular risk factors (Smoking, DM- 2, BMI, cholesterol level, ABI), Method(s) of assessing cognitive status: 3-stage screening beginning with CASI NINCDS-ADRDA Informant interview?: Yes | 1) Follow-up rate: 1932/2350=82% 2) Important baseline differences: More baseline stroke and low ABI in depressed or depressed and APOE-e4 positives 3) Outcome of interest #1: CESD 11>=9; HR for AD = 2.9 (95% CI 1.4 to 5.9) CESD 11>=9; HR for mixed AD =2.8 (95% CI 1.5 to 5.1) 4) Outcome of interest #2 The interaction term for depression and APOE-e4 was significant in the models above Neither Depression or APOE-e4, reference Only APOE-ef, HR for AD = 1.6 (0.8 to 3.1) Only CESD 11>=9, HR for AD = 2.2 (0.9 to 5.2) Both APOE and CESD 11 >=9, HR for AD 13.0 (4.3 to 39.5) | Comments: Do not adjust for gender Quality assessment: For observational studies: 1) Unbiased selection of the cohort: Partial 2) Selection minimizes baseline differences in prognostic factors: Yes 3) Sample size calculated/5% difference: No 4) Adequate description of the cohort: Yes 5) Validated method for ascertaining exposure: Yes 6) Validated method for ascertaining clinical outcomes: Yes 7) Outcome assessment blind to exposure: Can’t Tell 8) Adequate follow-up period: Yes 9) Completeness of follow-up: Yes 10) Analysis controls for confounding: Yes 11) Analytic methods appropriate: Yes
Jonker, Comijs and Smit, 2003 Longitudinal Aging Study Amsterdam (LASA) | Geographical location: 3 regions in The Netherlands Setting: Community Study design: Prospective cohort Number of participants enrolled: 612 Duration of follow up: 3 yrs Time from risk factor assessment to final cognitive assessment: BL 92/93, f/up 95/96 | Age: Mean (SD): NSAID− 72.6 (6.7) NSAID+ 73.1 (6.5) Range: 55 –85 Sex: [n (%)] Female: 328 (53.6%) Male: 284 (46.4%) Race/ethnicity: [n (%)] NR Baseline cognitive status: community dwelling, reasonable mmse scores Inclusion criteria: Born in 1930 or before; participated in the second data collection cycle of LASA; completed all cognitive tests at both times Exclusion criteria: This paper doesn’t really say. It implies that weighted (by expected mortality), random samples in three areas were pulled and didn’t eliminate anyone. Institutionalized subjects are not mentioned. | Risk factor/exposure 1: prescripton nsaids/asa Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Baseline mmse score, vascular disease, dm, RA Method(s) of assessing cognitive status: change in test score. Informant interview?: No | 1) Follow-up rate: Group chosen retrospectively from those will all information available. Group using nsaids both times and group not using prescription nsaids. 2) Important baseline differences: nsaid users had more vascular disease 3) Outcome of interest #1 information given for immed recall, delayed recall and coding tasks separately. The one that was “almost significant” showed an OR for NSAIDS for immed recall of 0.49 (0.23–1.05) | Comments: Only prescription nsaids counted. Mean mmse 26–27.5. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Partial 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Partial 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Kado, Karlalmangla, Huang, et al., 2005 MacArthur studies of successful aging. | Geographical location: Durham, North Carolina East Boston, Massachusetts New Haven, Connecticut Setting: Community Study design: Prospective cohort Number of participants enrolled: 1189 participated 499 with baseline data and 370 with longitudinal data analyzed Duration of follow up: 7 yrs Time from risk factor assessment to final cognitive assessment: 7 yrs | Age: Range: mean 74 yrs (SD=2.7 yrs) Sex: Female: 270 (54%) Male: 229 (46%) Race/ethnicity: NR Baseline cognitive status: population selected to be in the top third of physical and cognitive functioning for age group Inclusion criteria: 70 – 79 years old No disability on the Katz seven-item activities of daily living scale No more than one disability on eight self-report items regarding physical functioning Ability to hold a semi-tandem balance for ≥ 10 seconds Ability to stand from a seated position five times within 20 seconds Score of ≥ 6 on the 9-item Short Portable Mental Status Questionnaire Ability to remember at least three of six elements on a delayed recall of a short story Exclusion criteria: NR | Risk factor/exposure 1: hcy stored frozen plasma – nonfasting-for ~8yrs Method of assessing risk factor/exposure 1: Direct measurement Risk factor/exposure 2: B6, B12, and folate Method of assessing risk factor/exposure 2: Direct measurement Covariates/potential confounders adjusted for in analyses: in one model adjusted for age, sex, education, baseline physical fxn, smoking, in second model b 6 &12 and folate also added. Method(s) of assessing cognitive status: Change over time in the summary score from the following measures: Language 18 item Boston Naming test Abstraction: 4 items from the Similarities subtest of the Wechsler’s Adult intelligence scale Spatial ability: Copying image Incidental recall of confrontation naming Delayed recall of a story Informant interview?: No | 1) Follow-up rate: 370/499 with 79 dead, 29 with proxy interviews, 14 who refused and 7 did not complete testing 2) Important baseline differences: NR 3) Outcome of interest #1 HCY: with first set of covariates risk ratio of 7 yr cognitive decline 1.44 (0.91–2.09) with addition of B6, B12, and folate as covariates, rr for 7 yr cognitive decline with hcy 1.11 (0.65–1.76) 4) Outcome of interest #2 Folate: with first set of covariates risk ratio for 7 yr cognitive decline was 1.71 (1.13–2.37) With addition of B6, B12, and HCY as covariates, risk ratio for 7 yr decline was 1.60 (1.01–2.31) 5) Outcome of interest #3 Vitamin B6: with first set of covariates risk ratio for 7 yr cognitive decline was 1.20 (0.74–1.81) With addition of B12, folate, and HCY as covariates risk ratio for 7 yr cognitive decline was 1.02 (0.59–1.62) 6) Outcome of interest #4 Vitamin B12: with first set of covariates risk ratio for 7 yr decline was 1.42 (0.91–2.06) With addition of B6, folate and HCY as covariates risk ratio for 7 yr decline was 1.27 (0.82–1.92) | Comments: Participants were selected to be in top 1/3 of population, so applicability to general population is limited. Baseline cognitive status assessed by 9 question SPMSQ. To participate subjects had to have score ≥6, which would may not exclude mild dementia. Exposure measured on non-fasting samples that may not accurately reflect bioavailability of homocysteine Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Partial 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Kalmijn, Feskens, Launer, et al., 1997a Zutphen Elderly Study | Geographical location: Zutphen, Netherlands Setting: Community Study design: Cohort Number of participants enrolled: 718 Duration of follow up: 3 years Time from risk factor assessment to final cognitive assessment: 3 years | Age: Mean (SD): 74.6 (4.2) years Sex: [n (%)] Female: 0 (0%) Male: 718 (100%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Can’t tell Inclusion criteria: Male Living in Zutphen Exclusion criteria: NR | Risk factor/exposure 1: Education Method of assessing risk factor/exposure 1: self report Years of formal education: 1) ≤6 yrs 2) >6 yrs (reference) Risk factor/exposure 2: ApoE Method of assessing risk factor/exposure 2: Direct measurement Covariates/potential confounders adjusted for in analyses: Age h/o cardiovascular disease Method(s) of assessing cognitive status: MMSE in 1990 and 1990. Cognitive decline defined as a drop of 2 or more points. Informant interview?: No | 1) Follow-up rate: 560/718 (78%) in 1990, than 390/533) in 1993. Complete information in 356 2) Important baseline differences: NA 3) Outcome of interest #1 Association between education and cognitive decline in total group, and ApoE carriers vs. noncarriers. 4) Outcome of interest #2-- Education [underlined: Total population:] ≤6 yrs: OR 2.1 (95% CI: 0.9, 4.9) 5) Outcome of interest #3— Education and ApoE interaction [underlined: ApoE non carrier] (n=272) ≤6 yrs: OR 3.1 (95% CI: 1.1, 8.8) [underlined: ApoE carrier] (n-84) ≤6 yrs: OR 0.9 (95% CI: 0.2, 3.8) | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Partial, education arbitrarily dichotomized 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Kalmijn, Feskens, Launer, et al., 1997b Zutphen Elderly Study | Geographical location: Zutphen, Netherlands Setting: Community Study design: Prospective cohort Number of participants enrolled: 342 Duration of follow up: 3 yr Time from risk factor assessment to final cognitive assessment: 3–8 yrs (nutrition data used from 1985 and 1990 time point, final cognitive outcome 1993) | Age: NR Sex: [n (%)] Female: 0 (0%) Male: 342 (100%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented – most were probably non-demented – but some may have been demented Inclusion criteria: Born between 1900 and 1920 Completed 1990 and 1993 MMSE Exclusion criteria: NR | Risk factor/exposure 1: antioxidant and polyunsaturated fats Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Educational level Smoking ETOH use Energy intake Baseline cognitive status Method(s) of assessing cognitive status: Other – > 2 pt decline on MMSE indicated ‘cognitive decline’ Informant interview?: No | 1) Follow-up rate: 342/476 (but don’t know reason for attrition) 2) Important baseline differences: NR 3) Outcome of interest #1 No association between cognitive decline and linoleic acid, n-3 fatty acids, beta carotene, vitamins C and E, flavonoids. P for trends across low, medium and high tertile for each nutrient ranged from 09 – 0.9. | Comments: Question 2 Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: Can’t Tell 4) Adequate description of the cohort?: No 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Partial 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Partial 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Kalmijn, Launer, Lindemans, et al., 1999 Rotterdam Case control subgroup | Geographical location: suburban Rotterdam, The Netherlands Setting: Community Study design: Prospective cohort Number of participants enrolled: Baseline enrollment: 7983 Sample size for this study: 702 Duration of follow up: mean 2.7 (0.5) yrs. Time from risk factor assessment to final cognitive assessment: serum collected at baseline and stored for 4+ yrs | Age: Range: ≥ 55 years Sex: [n (%)] Female: 424.08 ( 60.5) Male: 277.92 (39.5) Race/ethnicity: NR Baseline cognitive status: case control, kind of. Random subset of cohort who had mmse done plus a group with mmse decline of <1 point per year. Inclusion criteria: Residents of Rotterdam Age 55 and older Exclusion criteria: Non Rotterdam Residents Age 54 and younger | Risk factor/exposure 1: hcy Method of assessing risk factor/exposure 1: Direct measurement of a nonfasting serum sample, frozen for 4.1 yrs (no decline) or 4.3 yrs (cog decline grp) Covariates/potential confounders adjusted for in analyses: Age, Sex, Educational level, Baseline mmse Method(s) of assessing cognitive status NINCDS-ADRDA DSM Informant interview?: No | 1) Follow-up rate: groups chosen that had data available. 2) Important baseline differences: more alcohol use in the random sample as opposed to decliners. 3) Outcome of interest #1 for middle third of hcy (12.9–15.7) as opposed to lowest tertile OR 1.14 (0.67 – 1.93), for highest third as compared to lowest third OR 0.91 (0.52 – 1.58) | Comments: They had a relatively brief period of follow up and selected for the most rapid cognitive decline. They selected random groups of those meeting a definition of decline and those who didn’t and ran hcy on these two groups on serum that they had stored at baseline. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: No 2) Selection minimizes baseline differences in prognostic factors?: No 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Kalmijn, Launer, Ott, et al., 1997 Rotterdam study | Geographical location: Rotterdam, Netherlands Setting: Community Study design: Prospective cohort Number of participants enrolled: 5386 Duration of follow up: 2.1 yr (0.8) Time from risk factor assessment to final cognitive assessment: 2.1 yr (0.8) | Age: Mean (SD): 67.7 (7.8) Sex: [n (%)] Female: 3182 (59%) Male: 2204 (41%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: ≥ 55 yr; resident of specific suburb in Rotterdam, had reliable nutritional data, not demented at baseline Exclusion criteria: Nursing home residents | Risk factor/exposure 1: Fat intake Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Total energy intake Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Informant interview?: Yes | 1) Follow-up rate: 5386 had all info – not clear f/u rate 2) Important baseline differences: NR 3) Outcome of interest #1 Used results for all dementia because mixed dementia (AD +vascular) included in these numbers Dementia (particularly that with a vascular component) associated with highest tertile of: Total fat: RR 2.4 (1.1–5.2) Saturated fat: RR 1.9 (0.9–4.0) Cholesterol: RR 1.7 (0.9–3.2) 4) Outcome of interest #2 Fish intake > 18.5 g/day associated with decreased risk of dementia (RR=0.4; 0.2–0.9) Linoleic acid – not associated with dementia (RR=0.6; 0.3–1.2) | Comments: Question 1 Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Can’t Tell 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Kang, Ascherio and Grodstein, 2005 Nurses Health Study | Geographical location: 11 US states Setting: Community Study design: Prospective cohort Number of participants enrolled: 13,388 Duration of follow up: 2 yrs (cognitive) Time from risk factor assessment to final cognitive assessment: Up to ~19 yrs (averaged diet intake from 1984 – first cognitive data (1995– 2001) –and then last cognitive interview from 1997–2003 | Age: Mean (SD): 74 yr (but only gives 3 quintiles – so this is an estimate) Sex: Female: 13,388 (100%) Male 0 (0%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented – (assume most were non-demented, but not stated in paper) Inclusion criteria: Parent sample: Nurses aged 30–55 in 1976 in 11 US states Current sample: ≥ 70 yr No hx of CVA Responded to most recent mailed questionnaire Exclusion criteria: NR | Risk factor/exposure 1: Fruit and vegetable Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: age, education, high blood pressure, high cholesterol, diabetes, coronary heart disease, hormone therapy, age at menopause, body mass index, smoking, antidepressant use, nonsteroidal antiinflammatory drug use, alcohol intake, physical activity, total energy intake, mental health and vitality indices of the 36- question short-form health survey (SF-36), and vitamin supplementation Method(s) of assessing cognitive status: TICS, episodic memory and composite test summary score Informant interview?: No | 1) Follow-up rate: 90% completed 2^nd^ cognitive wave of cognitive assessment 2) Important baseline differences: Highest fruit and vegetable consumption group (compared to lower groups) were more educated, less likely to take antidepressants, better health habits, greater use of vitamins and HRT, greater physical activity, less smoking 3) Outcome of interest #1 On global cognitive score, --highest quintile of vegetable intake showed less decline than the lowest quintile (mean difference 0.04 (p trend <0.01) -- highest quintile of green leafy veg showed less decline than lowest quintile (mean diff 0.05; p trend <0.001) --Highest quintile of legumes showed less decline than lowest quintile (mean diff 0.03; p trend 0.02) Highest quintile of cruciferous veg showed less decline (mean diff 0.04; 0.003 −0.07, but no sig trend) 4) Outcome of interest #2 On episodic memory highest quintile of cruciferous veg scored better (mean diff 0.05; p trend =0.02) Highest quintile on green leafy vegetables showed less decline (0.06, p trend <0.001) 5) Outcome of interest #3 On TICS highest quintile on green leafy vegetables showed less decline (0.23, p trend 0.003 | Comments: Question 2 Some of the differences in decline are very small – may not be clinically significant but is statistically significant because of the large sample Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: Can’t Tell 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Kang, Cook, Manson, et al., 2008 Women’s Antioxidant and Folic Acid Cardiovascular Study | Geographical location: throughout the US Setting: Community Study design: RCT-add on to RCT Test intervention Vitamin E Vitamin C Beta carotene Vitamin B (Folic acid, Vitamin B-6, Vitamin B- 12) Comparator intervention(s): placebo Number of participants enrolled: 2009 Duration of follow up: 6 yr (cognitive) Time from risk factor assessment to final cognitive assessment: 6.6 y (range 6.3–6.9) | Age: Mean (SD): 71.3 (4.2) Sex: [n (%)] Female: 2009 (100%) Male: 0 (0%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Normal Non-demented MCI CIND AAMI AACD Inclusion criteria: Female health professionals ≥ 40 yr with CVD or ≥ 3 coronary risk factors. Those who completed the run-in-phase okay and had no history of cancer, active liver disease, chronic kidney failure, or use of anticoagulants, and who were willing to fore-go use of other vitamin supplements – were accepted for randomization Exclusion criteria: NR | Risk factor/exposure 1: Vitamin B (folic acid, B- 6, B-12) Method of assessing risk factor/exposure 1: Direct measurement Covariates/potential confounders adjusted for in analyses: None Method(s) of assessing cognitive status: Other – Decline on cognitive measures Informant interview?: No | 1) Follow-up rate: 93% randomized completed 1^st^ cognitive assessment, 94% completed at least one fup, 83% completed at least 3 assessments. Cumulatively, though, just over 50% of those sample completed Wave 4 (this was partially due to a logistic issue) 2) Important baseline differences: No differences 3) Outcome of interest #1 B vitamin group did not differ from the placebo group on extent of cognitive decline on any cognitive measure | Comments: Question: Q5 For RCTs: 1) Baseline comparability?: Yes 2) Valid AD/cognitive outcomes assessment?: Yes 3) Subjects/providers blind?: Yes 4) Outcome assessors blind?: Yes 5) Incomplete data adequately addressed?: Yes 6) Differential dropout rate < 10%?: Yes 7) Overall dropout rate < 30%?: No 8) Conflict of interest reported and insignificant?: Yes 9) Randomization adequate?: Yes 10) Allocation concealment adequate?: Can’t tell
Kang, Cook, Manson, et al., 2006 Women’s Health Study | Geographical location: US locations Setting: Community Study design: RCT. 10-year study, but this is a cognitive function substudy initiated 5.6 yrs after randomization. Test intervention Vitamin E (600 IU every other day) ASA 100 mg every other day) Comparator intervention(s) placebo Number of participants enrolled: 6377 Duration of follow up: 4.0 yrs (range, 2.6–5.7) Time from risk factor assessment to final cognitive assessment: Time from randomization (beginning of exposure) to initial cognitive assessment was 5.6 yrs (range: 4.4–6.8 yrs). Time from randomization to final cognitive assessment was approximately 9.6 yrs. | Age: Mean (SD): Vit E 66.2 (4.0) Placebo 66.3 (4.1) Range: Vit E 66.1 – 89.9 Placebo 60.4 – 87.1 Sex: [n (%)] Female: 6377 (100%) Male: 0 (0%) Race/ethnicity: [n (%)] NR Baseline cognitive status: NR Inclusion criteria: ≥ 45 yo; no history of coronary heart disease, cerebrovascular disease, cancer (except non-melanoma skin cancer), or other major chronic illnesses; did not actively use any of the study medications or have any history of adverse effects from the medications Exclusion criteria: NR | Risk factor/exposure 1: Vitamin E supplementation, 600 IU every other day, as part of RCT. Subjects also took aspirin 100 mg every other day in a factorial design. Method of assessing risk factor/exposure 1: RCT intervention Covariates/potential confounders adjusted for in analyses: NA (RCT) Method(s) of assessing cognitive status: 5 tests measuring general cognition, verbal memory, and category fluency. Primary, prespecified outcome was a global composite score averaging performances across all 5 cognitive tests using z scores. Informant interview?: No | 1) Follow-up rate: 5073/7175 (70.7%) of those initially enrolled completed all 3 assessments. 5073/6377 (80.0%) of those who completed initial baseline evaluation. 2) Important baseline differences: None 3) Outcome of interest #1 No between-group scores on the 5 tests at any of the 3 assessments. Also no between-group differences in mean change in cognitive performance. Mean difference in cognitive change global score at final assessment was 0.00 (−0.04 to 0.04) Compared with the placebo group, the vitamin E group did not have a lower risk of substantial cognitive decline from the first through third assessment and had a relative risk (RR) of substantial decline in global score of 0.92 (95% CI, 0.77 to 1.10). For the verbal memory score, the vitamin E group had a borderline significant 15% lower risk of substantial decline compared with the placebo group (RR, 0.85; 95% CI, 0.71 to 1.02). | Comments: 10-year study, but this is a cognitive function substudy initiated 5.6 yrs after randomization. Quality assessment: For RCTs: 1) Baseline comparability?: Yes 2) Valid AD/cognitive outcomes assessment?: Yes 3) Subjects/providers blind?: Yes 4) Outcome assessors blind?: Yes 5) Incomplete data adequately addressed?: Yes 6) Differential dropout rate < 10%?: Yes 7) Overall dropout rate < 30%?: Yes 8) Conflict of interest reported and insignificant?: Yes 9) Randomization adequate?: Yes 10) Allocation concealment adequate?: Yes
Kang, Cook, Manson, et al., 2009 Women’s antioxidant cardiovascular study (WACS) | Geographical location: Various US locations Setting: Other – female nurses with history cardiovascular disease Study design: RCT Test intervention : vitamin E 402mg Beta carotene 50mg Vitamin C 500mg Comparator intervention(s): Matching placebo Number of participants enrolled: 1586 Duration of follow up: 5.4 years Time from risk factor assessment to final cognitive assessment: 8.9 years (7.8–9.6) | Age: Mean (SD): 69 at randomization Sex: [n (%)] Female: 1586 (100%) Male: 0 (0%) Race/ethnicity: [n (%)] 94.0% white, 3.3% black, 0.9% Latino American, 0.7% Asian American, 1.1% other/multiple races Baseline cognitive status: Non-demented Inclusion criteria: Women, aged 40 and over, at high risk, with a history of coronary artery disease, carotid endarterectomy, peripheral artery surgery, or three or more coronary heart disease risk factors Exclusion criteria: Subjects were randomized only if they reported good compliance, willingness to continue in the trial, had no history of cancer, active liver disease, or use of coumadin, and expressed continued willingness to forego the use of beta- carotene and vitamin A, C, or E supplements. | Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Baseline cognitive status Method(s) of assessing cognitive status: Other – The primary outcome was a global composite score averaging all test scores (TICS, 10 word list delayed recall, East Boston Memory immediate and delay, category fluency animals) Informant interview?: No | 1) Follow-up rate: Compliance 64–68% across treatment 2) Important baseline differences: none 3) Outcome of interest #1 The primary outcome was a global composite score averaging all scores; repeated-measures analyses were used to examine cognitive change over time. Vitamin E supplementation and beta carotene supplementation were not associated with slower rates of cognitive change (mean difference in change for vitamin E versus placebo, −0.01; −0.05 to 0.04; P=0.78; for beta carotene, 0.03; −0.02 to 0.07; P=0.28). Although vitamin C supplementation was associated with better performance at the last assessment (mean difference, 0.13; 0.06 to 0.20; P=0.0005), it was not associated with cognitive change over time (mean difference in change, 0.02; −0.03 to 0.07; P_0.39). | Comments: Question 2 – no cat Dx Quality assessment: For RCTs: 1) Baseline comparability?: Yes 2) Valid AD/cognitive outcomes assessment?: Yes 3) Subjects/providers blind?: Yes 4) Outcome assessors blind?: Yes 5) Incomplete data adequately addressed?: Yes 6) Differential dropout rate < 10%?: Yes 7) Overall dropout rate < 30%?: Yes 8) Conflict of interest reported and insignificant?: No, conflict statement not given. 9) Randomization adequate?: Yes 10) Allocation concealment adequate?: Can’t Tell
Kang and Grodstein, 2008 Nurses’ Health study subgroup | Geographical location: 11 US sites Setting: Community Study design: Prospective cohort Number of participants enrolled: 858 Duration of follow up: 4 years for cognitive decline analysis Time from risk factor assessment to final cognitive assessment: Mean of 10 years between blood draw and initial cognitive interview. | Age: Mean (SD): 65 Sex: [n (%)] Female: 858 (100%) Male: 0 (0%) Race/ethnicity: [n (%)] NR Baseline cognitive status: No reported exclusion for dementia. Inclusion criteria: Enrolled in Nurses’ Health Study cognitive study; no history of stroke. Data from patients included in the cognitive function subcohort. Exclusion criteria: Those who did not provide blood samples; those who did not have plasma carotenoids and tocopherols measured; those who were cases of heart disease, breast cancer and colon cancers in nested-case control studies | Risk factor/exposure 1: Plasma antioxidant levels Method of assessing risk factor/exposure 1: Direct measurement 1) Total carotenoids 2) Five individual carotenoids Covariates/potential confounders adjusted for in analyses: Age Elapsed time Education Clinical variables Smoking Medications Alcohol Physical activity Method(s) of assessing cognitive status: Initially, TICS for screening. Then gradually added 5 other cognitive tests to initial screening. 3 main outcomes: 1) global performance on test battery; 2) verbal memory; 3) TICS Informant interview?: No | 1) Follow-up rate: 788/858 = (91.8%) 2) Important baseline differences: NA 3) Outcome of interest #1— Cognitive decline “Higher plasma levels of carotenoids or tocopherols were not associated with slower decline in cognition.” See Table 5 for mean differences in rate of CD over 4 years by quartile of plasma carotenoids and tocopherols. | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Karlamangla, Miller- Martinez, Aneshensel, et al., 2009 Assets and Health Dynamics Among the Oldest Old (AHEAD) Study | Geographical location: USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 6476 Duration of follow up: 9 years Time from risk factor assessment to final cognitive assessment: 9 years | Age: Mean (SD): 77.1 Sex: [n (%)] Female: 3970 (61.3%) Male: 2506 (38.7%) Race/ethnicity: [n (%)] -Non-Hispanic white 5712 (88.2%) -Non-Hispanic black 492 (7.6%) -Mexican Hispanic 110(1.7%) -Other Hispanic 91 (1.4%) -Other 71 (1.1%) Baseline cognitive status: Non-demented (some possibly demented) Inclusion criteria: Participants in the AHEAD study born before 1924 Exclusion criteria: -Institutionalized persons -Proxy cognition testing - Missing more than one cognition subscale | Risk factor/exposure 1: Demographic information (Age, sex, marital status, race/ethnicity) Method of assessing risk factor/exposure 1: Self reported Risk factor/exposure 2: Socio Economic Status (SES) as measured by highest year of school/college completed, household wealth, and annual household income. Method of assessing risk factor/exposure 2: Self-reported Covariates/potential confounders adjusted for in analyses: -Baseline low performance -Length of participation -Imputed scores Age Gender Ethnicity Marital status, Change in marital status Survivorship Method(s) of assessing cognitive status: -an abbreviated version of the Telephone Interview for Cognitive Status for participants aged 79 years or younger and in-person interviews for participants older than 79 years Informant interview?: No | 1) Follow-up rate: 2353/6476=36.3% at all visits; 81% had at least 1 follow-up 2) Important baseline differences: Did not report comparisons by exposure level 3) Outcome of interest #1 Mean decline with aging in total cognition score (range,0–35, SD, 6.00)= =4.1( 0.68 SD) per decade(95%CI,3.8,4.4) Older cohorts, women, widows/widowers, and those never married declined faster and non- Hispanic blacks and those in the bottom income quartile declined slower. 4) Outcome of interest #2 Mean decline in total cognition score with race, income and educational level (SES, socioeconomic status) Large SES differences in baseline scores did not translate to differences in rates of cognitive decline | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: No 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes.
Khachaturian, Zandi, Lyketsos, et al., 2006 Cache Co. | Geographical location: Cache County, Utah Setting: Community Study design: Prospective cohort Number of participants enrolled: 5092 at baseline; 3297 participating in this substudy Duration of follow up: 3 yrs Time from risk factor assessment to final cognitive assessment: pill bottle checked and cog eval both waves | Age: Range: ≥ 65 years Sex: Female: 59% Male: 41% Race/ethnicity: NR Baseline cognitive status: Non-demented Inclusion criteria: Participating in the Cache County Study Exclusion criteria: NR | Risk factor/exposure 1: antihypertensives Method of assessing risk factor/exposure 1: inspection of pill bottles for “current” use. Covariates/potential confounders adjusted for in analyses: Age, Race, Sex, number of apo E4s, hx of cva, hyperlpidemia, dm, mi, Educational level Method(s) of assessing cognitive status: NINCDS-ADRDA Informant interview?: not for everybody but IQCODE if unable to participate in screening and DQ if 3ms positive | 1) Follow-up rate: 5092 baseline, 355 demented, 627 died, 802 refused to complete study, 2) Important baseline differences: antihtn users older, less educ, fewer women, more strokes, more hyperlipidemia, more dm. more mi, more apoE4 than non antihypertensives 3) Outcome of interest #1 antihypertensive use and incident AD HR 0.64 (0.41–0.98) | Comments: Question 1 Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Kivipelto, Ngandu, Fratiglioni, et al., 2005 AND Kivipelto, Helkala, Laakso, et al., 2001 CAIDE & North Karelia Project | Geographical location: Kuopio & Joensuu, Finland Setting: Community Study design: Prospective cohort Number of participants enrolled: 1449 Duration of follow up: 21 yrs (4.9) from baseline interview until cog assessment Time from risk factor assessment to final cognitive assessment: 21 yrs, range 11–26 yrs | Age: Mean (SD): Baseline: 50.6 (6.0) Follow-up: 71.6 (4.1) Sex: [n (%)] Female: 900 (62%) Male: 549 (38%) Race/ethnicity: [n (%)] NR Baseline cognitive status: unclear, but baseline measures were done in mid life when cog impairment would be unlikely Inclusion criteria: Survivors of 4 separate samples of the North Karelia Project and FINMONICA study; lived in two geographically defined areas; permission for BP and blood specimens to be taken Exclusion criteria: NR | Risk factor/exposure 1: htn, BMI Method of assessing risk factor/exposure 1: Direct measurement Normal sbp < 140, borderline 140–159, high >159, normal dbp < 90, borderline 91–94. High > 94 Direct measurement; BMI calculated based on weight/height; Categorized as >30; 25–30 and <25 Risk factor/exposure 2: cholesterol; high = >=6.5 mmol/l Method of assessing risk factor/exposure 2: Direct measurement Covariates/potential confounders adjusted for in analyses: Age, sex, education, and follow-up interval, Some analysis adjusted for APOE, hx MI, hx DM, hx stroke, midlife SBP and DBP, cholesterol, smoking, and ETOH use Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Informant interview?: No | 1) Follow-up rate: 1449/2000 invited participated (72.5%); f/u rate from original cohort cannot be determined 2) Important baseline differences: At baseline, higher BMI associated with increased age, shorter follow-up interval, higher SBP and DBP, and lower education 3) Outcome of interest #1. Risk of AD 57 incident dementia (48 AD) Midlife borderline sbp OR 2.1 (0.8–5.0), high sbp 2.8 (1.1 – 7.2) 4) Outcome of interest #2 Midlife borderline dbp 1.4 (0.6 – 3.5) high dbp 1.7 (0.8 – 3.6) 5) Outcome of interest #3 midlife cholesterol ≥ 6.5 mml/l OR 2.2 (1.0–4.7) Both high BP (>159) and high cholesterol (>=6.5 mml/l) compared to one risk factor; OR=3.5 (1.6 to 7.9) 6) Outcome of interest #4: Obesity and incidence of AD BMI > 30: OR adjusted for covariates listed + APOE = 1.88 (95% CI 0.76 to 4.63) BMI 25–30 not associated with incident AD, OR=0.99 (0.47 to 2.15) 7) Outcome of Interest #5: Number of midlifed vascular risk factors (BMI>30, BP >140, T Chol >252) adjusted for age, sex, education and follow-up time: OR for 1 risk factor = 1.37 (0.44 to 4.27); 2 risk factors OR=3.03 (1.03 to 8.89); 3 risk factors OR=6.21 (1.94 to 19.92) | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Partial 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Knopman, Boland, Mosley, et al., 2001 ARIC | Geographical location: Forsyth County, NC Jackson, MS Suburban Minneapolis, MN Washington County, MD Setting: Community Study design: Prospective cohort Number of participants enrolled: 10,963 Duration of follow up: mean 6 years (0.3). Time from risk factor assessment to final cognitive assessment: 6 years | Age: Range: 47–70 Sex: NR Race/ethnicity: 8729 white (79.6%) 2234 black (20.4%) Baseline cognitive status: Population formed 45–64 years of age, no cog requirements. Inclusion criteria: Enrolled in ARIC Study Exclusion criteria: History of stroke or TIA | Risk factor/exposure 1: nsaids Method of assessing risk factor/exposure 1: self report, pill bottles Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Site, cns-relevant meds (antipsychotics, antidepressants, anxioulytics, opiates, anticonvulsants, antineoplastic agents). Method(s) of assessing cognitive status: Change in individual thests Informant interview?: no | 1) Follow-up rate: 76% at six years 2) Important baseline differences: not well recorded This paper covers multiple risk factors 3) Outcome of interest #1 nsaid use not associated with declines on any test. | Comments: ASA included with nsaids, Change in individual tests. Mean change in test by risk factor given. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Partial 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Yes 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Knopman, Mosley, Catellier, et al., 2009 ARIC study subset | Geographical location: 4 US communites: Forsyth county, NC; Jackson, MS; Minneapolis, MN; & Washington county, MD Setting: Community Study design: Prospective cohort Number of participants enrolled: 1130 Duration of follow up: Median of 14 years Time from risk factor assessment to final cognitive assessment: 14 years | Age: Mean (SD): 59 (4.3) Sex: [n (%)] Female: 701 (62%) Male: 429 (38%) Race/ethnicity: [n (%)] African/Amer: 588 (52%) Other: 542 (48%) Baseline cognitive status: Normal Inclusion criteria: Subset of the ARIC cohort who participated in two brain MRI studies between 1993–1995 and 2004–2006. Exclusion criteria: Prior surgery for an aneurysm in the brain; metal fragments in the eyes, brain, or spinal cord; valvular prosthesis; cardiac pacemaker; cochlear implant; spinal-cord stimulator, or other internal electrical device; pregnancy; occupations associated with exposure to metal fragments | Risk factor/exposure 1: APOE genotype Method of assessing risk factor/exposure 1: TaqMan assay Risk factor/exposure 2: Vascular risk factors at baseline Method of assessing risk factor/exposure 2: Diabetes: Fasting glucose >126 mg/dl or nonfasting glucose >200 dl or self-reported h/o diabetes or treatment for diabetes in previous 2 weeks. HTN: SBP >140 mm HG or DBP >90 or any use of antihypertensive medication in previous 2 weeks. Education: self report (<12 yrs), 12–16 yrs, ≥17 yrs) Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Vascular factors Time Risk factor x time interaction Method(s) of assessing cognitive status: Digit Symbol Substitution (DSS); Delayed Word Recall (DWR); Word Fluency (WF) Informant interview?: No | 1) Follow-up rate: 15,792 at visit 1. 12,887 in visit 3; of these, 2891 participants aged 55 and older invited for MR imaging. 1945 completed an MR, with 1920 usable scans. 1130 completed visit 4, for a rate of 1130/1920 = 59%. 2) Important baseline differences: N/A 3) Outcome of interest #1 Difference in average baseline cognitive test scores (P value): [underlined: APOE genotype] DSS: 1.06 (0.03) DWR: 0.17 (0.49) WF: 0.59 (0.405) 4) Outcome of interest #2 Difference in average baseline cognitive test scores (P value): [underlined: Diabetes] DSS: 0.25 (0.803) DWR: −0.19 (0.173) WF: 0.60 (0.597) 5) Outcome of interest #3 Difference in average baseline cognitive test scores (P value): [underlined: HTN] DSS: 1.55 (0.016) DWR: 0.15 (0.089) WF: −0.123 (0.088) 6) Outcome of interest #4 Difference in average baseline cognitive test scores (P value): [underlined: Education level] DSS: 6.87 (<0.001) DWR: 0.33 (<0.001) WF: 7.71 (<0.001) | Comments: Question 2 – no cat Dx. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Can’t tell, unclear how MRI subsample selected. 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Koster, Penninx, Bosma, et al., 2005 Health, Aging and Body Composition study (Health ABC) | Geographical location: Pittsburg, PA Memphis, TN Setting: Community Study design Prospective cohort Number of participants enrolled: 2574 enrolled subjects out of longitudinal cohort of 3075. Duration of follow up: 4 yrs Time from risk factor assessment to final cognitive assessment: 4 yrs | Age: Range: 70–79 yrs old Sex: both included but numbers NR Race/ethnicity: Black and white but actual numbers NR Baseline cognitive status: Non-demented Inclusion criteria: Well-functioning: no difficulty walking one- quarter mile or going up 10 steps without resting. Exclusion criteria: -Active treatment for cancer most recent 3 yrs -Planned move out of study area in next 3yrs -Current participation in randomized trial of lifestyle intervention | Risk factor/exposure 1: Education Categories: <12 yrs education 12 yrs education >12 yrs education Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Baseline cognitive status Study site House hold income Biomedical factors Method(s) of assessing cognitive status: Other – Modified Mini- Mental State Examination(3MS) Informant interview?: No | 1) Follow-up rate: 2088 followed up yr 4(81.1%) 486 lost to follow up (18.9%) 2) Outcome of interest #1 Cognitive decline was defined as a decrease of 5 or more points on the 3MS between baseline and 4^th^ yr follow up. Adjusted odds ratio were significantly higher in those with low education: >12 yrs education: OR 1.00 12 yrs education: OR 1.42 (1.10–1.83) <12 yrs education: OR 2.16 (1.59–2.94 All CI 95% Two models were used for OR assessment based on slightly different covariates. Results were very similar. | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Partial 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Kritz- Silverstein, von Muhlen, Laughlin, et al., 2008 DAWN Trial | Geographical location: San Diego, CA Setting: Clinical Research Facility Study design: RCT Test intervention: 50 mg oral DHEA daily Comparator intervention(s): placebo Number of participants enrolled: 225 Duration of follow up: 1 yr Time from risk factor assessment to final cognitive assessment: 12 mos | Age: Mean (SD): 68 yr (8) Median: Range: 55–85 yrs Sex: [n (%)] Female: 115 (51%) Male: 110 (49%) Race/ethnicity: [n (%)] NR Baseline cognitive status Normal Inclusion criteria: Aged 55–85; non- smokers; not currently using any hormone therapy Exclusion criteria: NR | Risk factor/exposure 1: DHEA (dehydro Epiandrosterone) Method of assessing risk factor/exposure 1: RCT Risk factor/exposure 2: RCT Method of assessing risk factor/exposure 2: RCT Covariates/potential confounders adjusted for in analyses RCT Method(s) of assessing cognitive status: Other – modified MMSE; word list; word list recall; verbal fluency; boston naming; trails b Informant interview?: No | 1) Follow-up rate: compliance with treatment 95% treatment, 94% placebo; 23 DHEA treatment stopped adverse events; 10 placebo stopped. Followup rate for treatment group 79.5%; placebo 91.2%. Follow up rate not reported by sex. 2) Important baseline differences: Possibly relevant- DHEA levels in treated woman higher at baseline than placebo (p<0.003); testosterone higher in treated woman than placebo (p<.01) 3) Outcome of interest #1 Outcome comparisons made using Wilcoxon tests. No differences in treatment and placebo groups in any cognitive measure in either sex. Modified MMSE- no difference dhea treated and placebo 4) Outcome of interest #2 Word List- no difference dhea treated and placebo 5) Outcome of interest #3, 4, 5, 6 Word List Recall - no difference dhea treated and placebo Verbal Fluency - no difference dhea treated and placebo Boston Naming - no difference dhea treated and placebo Trails B - no difference dhea treated and placebo | Comments: None Quality assessment: For RCTs: 1) Baseline comparability? Yes 2) Valid AD/cognitive outcomes assessment? Yes 3) Subjects/providers blind? Yes 4) Outcome assessors blind? Yes 5) Incomplete data adequately addressed? Yes 6) Differential dropout rate < 10%? No. DHEA group 79.5% placebo 91.2% 7) Overall dropout rate < 30%? Yes 8) Conflict of interest reported and insignificant? Yes 9) Randomization adequate? Yes 10) Allocation concealment adequate? Yes
Kroger, Verreault, Carmichael, et al., 2009 Candadian Study of Health and Aging | Geographical location: 36 Canadian provinces Setting: Community Other 0 institutionalized individuals Study design: Nested case-control Number of participants enrolled: For 8361 non- demented, 1219 provided blood samples, 663 analytical sample Duration of follow up: Median of 4.9 years (IQ range 4.5–5.2) Time from risk factor assessment to final cognitive assessment: Median 4.9 years; max 10 years | Age: Mean (SD): 80 (6.0) normals; 82.5 (6.6) dementia Sex: [n (%)] Female: 401 (61%) Male: 262 (39%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Age ≥ 65 yo Living in community or in institutions in 1991 Provided blood sample Selected for full neuropsychiatric examination Exclusion criteria: Dementia No viable blood sample Did not complete ≥1 follow-up | Risk factor/exposure 1: Total n-3 PUFAS and erythrocyte membrane omega-3 PUFAs at baseline analyzed by quartiles, above below median and as continuous variables. Method of assessing risk factor/exposure 1: Direct measurement Risk factor/exposure 2: Blood mercury levels Method of assessing risk factor/exposure 2: Direct measurement Covariates/potential confounders adjusted for in analyses: Age Sex Educational level APOE e4, BMI, ever smoking, ETOH, diabetes mellitus, HTN, CVD, h/o stroke or MI, depression, family h/o dementia Method(s) of assessing cognitive status: 2-stage screening with neuropsychological evaluation for those with abnormal 3MS and random sample of normals. NINCDS-ADRDA: AD DSM-Dementia Informant interview?: Yes | 1) Follow-up rate: 1219 with blood samples; 450 died, 68 lost to follow-up, 31 had blood samples that were missing or could not be analyzed; 663/1219 = 54% 2) Important baseline differences: NR by exposure category; this subsample had slightly less education than overall cohort 3) Outcome of interest #1 149 incident cases of dementia (105 AD) HR (95% CI) for quartiles of total n-3 PUFAs and AD Quartile 1: ref Quartile 2: 1.36 (0.79–2.35) Quartile 3: 0.97 (0.55–1.71) Quartile 4: 1.12 (0.63–1.98) No association for all cause dementia 4) Outcome of interest #2 HR (95% CI) for quartiles of docosahexanoic acid and AD Quartile 1: ref Quartile 2: 0.81 (0.47–1.38) Quartile 3: 0.77 (0.44–1.35) Quartile 4: 0.81 (0.47–1.40) No association for all cause dementia 5) Outcome of interest #3 HR (95% CI) for quartiles of eicosapentaenoic acid and AD Quartile 1: ref Quartile 2: 1.16 (0.68–1.98) Quartile 3: 0.98 (0.56–1.71) Quartile 4: 0.89 (0.49–1.59) No association for all cause dementia 5) Outcome of interest #4 HR (95% CI) for quartiles of blood mercury and AD Quartile 1: ref Quartile 2: 0.76 (0.46–1.26) Quartile 3: 0.41 (0.23–0.74) Quartile 4: 0.56 (0.32–0.99) Higher mercury concentration also associated with lower risk for all cause dementia | Comments: Question 1 This is an updated analysis of Laurin 2003; sample significantly larger;. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Partial 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Partial, race not given 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Partial, time lag for mercury effects uncertain 9) Completeness of follow-up? Partial 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Kuo, Jones, Milberg, et al., 2005 AdvancedCognitiveTrainingFor Independent and Vital Elderly(AC TIVE) | Geographical location: Six field sites in US Setting: Community Study design: Observational analysis (cohort) from a RCT Comparator intervention(s) All participants were randomized into three cognitive intervention groups (memory training, reasoning training or speed or processing training) and a no-contact control group. Number of participants enrolled: 2802 Duration of follow up: Annually for 2 yrs Time from risk factor assessment to final cognitive assessment: 2 yrs | Age: Mean (SD): 73.6+/−5.9 Range: 65–94 yrs old Sex Female: 2126(75.9%) Male: 676(24.1%) Race/ethnicity: White: 2017(72.0%) African American: 724 (25.8%) Hispanic: 15(0.5%) Other: 46(1.7%) Baseline cognitive status: Non-demented Inclusion criteria: 65 yrs and older, non- demented Exclusion criteria: <65yrs,< 23 on MMSE, known diagnosis of AD, functionally impaired, medically unstable, recent or current participation in other cognitive training, visual, hearing or communicative impairment | Risk factor/exposure 1: Blood pressure Method of assessing risk factor/exposure 1: Direct measurement: obtained from a trained research assistant Risk factor/exposure 2: Diabetes Mellitus: Method of assessing risk factor/exposure 2: Self-report: obtained by asking direct question to subjects Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Baseline cognitive status Study site Intervention group Cardiovascular risk factors Tobacco use BMI Method(s) of assessing cognitive status: Other – MMSE: measured global cognitive function; Reasoning domain used word series, letter series and letter sets. A higher reasoning composite score indicates better performance. Speed of processing assessed using Useful Field of View(UFOV) Informant interview?: No | 1) Follow-up rate: NR 2) Important baseline differences: NA 3) Outcome of interest #1—10 mm increase in SBP Beta coefficient (SE), p value MMSE: −0.021 (0.016), p=.19 Memory composite: −0.020 (0.019), p=.30 Reasoning composite: −0.049 (0.019), p=.008 Speed of processing Digit Symbol Substitution test: −0.020 (0.082), p=.80 Useful Field of View: 3.049 (2.170), p=.16 4) Outcome of interest #2-- Diabetes Beta coefficient (SE), p value MMSE: −.0.305 (0.108), p=.005 Memory composite: −.303 (0.130), p=.02 Reasoning composite: −0.108 (0.126), p=.39 Speed of processing Digit Symbol Substitution test −2.371 (0.559), p<.001 Useful Field of View: 60.936 (14.647), p<.001 | Comments: Patients with more severe dm or htn excluded Participant in RCT of cognitive training Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Partial: DM based on unvalidated self- report 6) Validated method for ascertaining clinical outcomes? Partial: the useful field of vision test is not well validated test for this outcome. 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Confounding? Yes 11) Analytic methods appropriate? Yes
Laitinen, Ngandu, Rovio, et al., 2006 CAIDE Study | Geographical location: North Karelia and Kuopio provinces, Finland Setting: Community Study design: Prospective cohort Number of participants enrolled: 2000, but 1,449 participated in follow- up. Included all in analyses Duration of follow up: 21 (4.9) yrs (for the 1,449) Time from risk factor assessment to final cognitive assessment: 21(4.9) yrs | Age: (for 1,449) Mean (SD): midlife exam: 50.4 (6.0) yr fup exam: 71.3 (4.0) Sex: [n (%)] Female: 900 (62.1%) Male: 549 (37.9%) Race: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Participated in one of two other population- based studies. Alive, e, aged 65 to 79 at the end of 1997 and living in one of two geographically defined areas in or close to the towns of Kuopio and Joensuu in Finland. Exclusion criteria: NR | Risk factor/exposure 1: Fat intake Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age (midlife) Sex Educational level FUP time Milk fat and other types of fats from spreads Midlife vascular risk factors APOE History of vascular disorders collected at f/u Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Other: ~551 non- participants at FUP, dx from medical records, assume still tried to apply above criteria Informant interview?: No (neither this article nor the methods paper mentions an informant interview) | 1) Follow-up rate: not relevant because the included non-participants in analyses – 2000 selected from baseline study to be followed ~21 yr later 2) Important baseline differences: At baseline, individuals who became demented older, less educated, had higher BMI, higher, SBP, higher cholesterol than non-demented 3) Outcome of interest #1 Total fat: 2^nd^, 3^rd^ and 4^th^ quartiles of total fat intake was not associated with increased risk of AD (compared to 1^st^ quartile) PUFA: 3^rd^ quartile of PUFA associated with lower risk of AD (OR- 0.36; 0.16–0.82) MUFA: 2^nd^, 3^rd^ and 4^th^ quartiles of MUFA was not associated with increased risk of AD (compared to 1^st^ quartile) SFA: 2^nd^ quartile of SFA was not associated with increased risk of AD(compared to 1^st^ quartile) | Comments: Question: Q1 Results section states that the results were very similar when analyses were limited to those who participated in the follow-up. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Partial. More details on non-participants at f/u needed. 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? No 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Partial. Used all subjects, even non-participants at f/u. 10) Analysis controls for confounding? Partial. Not sure how late life medical conditions were determined for the non- participants. 11) Analytic methods appropriate? Yes
Larson, Wang, Bowen, et al., 2006 ACTS (Adult Changes in Thought Study) | Geographical location: Seattle, WA Setting: Clinical—Group Health Cooperative HMO Study design: Prospective cohort Number of participants enrolled: 5422 eligible, 2581 participated (2841 declined) in ACT study. 1740 in final sample, from 1895 persons in the ACT study whose CASI scores were above the 25^th^ percentile. 155 withdrew after the baseline visit. Duration of follow up: 6.2 yrs (SD, 2.0) Time from risk factor assessment to final cognitive assessment: 6.2 yrs (SD, 2.0) | Age: Mean (SD): [underlined: Free of dementia]: 73.2 (5.1). [underlined: With dementia:] 78.2 (5.5) Sex: Female: [underlined: Free of dementia]: 731 (61.9%) [underlined: With dementia:] 93 (58.9%) Male: [underlined: Free of dementia]: 454 (38.1%) [underlined: With dementia]: 65 (41.1%) Race/ethnicity: [underlined: Free of dementia]: [underlined: White]: 1109 (93.7%) [underlined: Black]: 20 (1.7%) [underlined: Other]: 55 (4.6%) Baseline cognitive status: Normal Non-demented Inclusion criteria: Age ≥ 65 when study began in 1994–1996. Member of Group Health Coop HMO. Participants in ACT study with CASI scores above the 25^th^ percentile. Exclusion criteria: Existing diagnosis of dementia current residents of a nursing home participation in other studies. | Risk factor/exposure 1: Physical exercise. Method of assessing risk factor/exposure 1: Self-report: # of days per week they did each of list of activities for at least 15 minutes at a time during the past year. Scale dichotomized “exercised regularly” defined as self-report of exercise ≥3 times/wk, vs. “did not exercise regularly.” Covariates/potential confounders adjusted for in analyses: Age Ethnicity Sex Educational level Baseline cognitive function Physical function Depression Health conditions Lifestyle characteristics Supplements APOE Method(s) of assessing cognitive status: Screened with CASI. Screen positives (CASI < 86) had additional medical record review and standardized clinical and neuropsych eval. “Cognitively intact” if CASI ≥86. NINCDS-ADRDA DSM-IV Informant interview?: No | 1) Follow-up rate: 1740/1895 (92%). 155 withdrew after baseline visit. Random sample of 6782 members of GHC Excluded: dementia, nursing home, or participating in other studies (1360). Of 5422 eligible, 2581 participated and 2841 declined (no difference in age, sex, or ethnicity, but older, women, and minority more likely to decline). Excluded lowest quartile of CASI scores (n=686). 2) Important baseline differences: NA 3) Outcome of interest #1 158 incident cases of dementia (107 of which were AD and 33 were vascular dementia and 18 were other). Incidence rate 13.0/1000 person-yrs for dementia. 4) Outcome of interest #2-- Dementia Incidence rate 13.0/1000 person-yrs for persons who exercised ≥3 times/wk vs. 19.7/1000 person-yrs for persons who exercised <3 times/wk. Age- and sex-adjusted HR was 0.62 (95% CI, 0.44–0.86, p=0.004). HR was 0.68 (95% CI, 0.48–0.96) when adjusted for all potential confounders. Kaplan-Meier survival estimates show that exercising ≥3 times/wk is associated with higher probability of being dementia-free. Significant interaction between exercise and performance-based physical function (p=0.013). Risk reduction associated with exercise was greater in those with lower performance levels. 5) Outcome of interest #3--AD Age- and sex-adjusted HR was 0.64 (95% CI, 0.43–0.96, p=0.031). HR was 0.69 (95% CI, 0.45–1.05; p=0.081) when adjusted for all potential confounders. The interaction of exercise with performance-based physical function was significant (p=0.021). | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? No 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Launer, Ross, Petrovich, et al., 2000 Honolulu Heart Program | Geographical location: Honolulu, HI Setting: Community Study design: Prospective cohort Number of participants enrolled: 8006 in initial cohort; 3703 in this analysis Duration of follow up: >=23 years Time from risk factor assessment to final cognitive assessment: average of 27 years between first bp measurement and the dementia assessment | Age: Mean (SD): 52.7 (4.7) at baseline exam; 77.9 (4.7) at outcome assessment Range: 71 – 93 yo Sex: [n (%)] Female: 0% Male: 100% Race/ethnicity: [n (%)] Japanese-American (100%) Baseline cognitive status: no elimination of cognitive impairment but mean age at baseline 52.7±4.7 Inclusion criteria: Participant in Honolulu Heart Program; Japanese-American males; born between 1900 – 1919; living in Oahu, HI at baseline; military service registered from WWII Exclusion criteria: 30 subjects with dementia due to PD, b12 defiiency, subdural hematoma, or supranuclear palsy) | Risk factor/exposure 1: Measured each visit 3 times five min apart, dbp “recorded as the fifth phase” Low sbp <110, normal 110–139, borderline 140–159, high 160+, dpb low <80, nl 80–89, borderline 90–94, high 95+ A fifth category was created for those whose bp did not fall into a category above in 2/3 measurements. Self report of antihypertensives. Method of assessing risk factor/exposure 1: Direct measurement Covariates/potential confounders adjusted for in analyses: Age (at the fourth exam), education, apolipoprotein phenotype, smoking thru exam 3, alcohol at exam 3, cva, cad, subclinical atherosclerosis (abi based) Method(s) of assessing cognitive status: DSMIII-R - dementia NINCDS-ADRDA- AD Informant interview?: Yes – for those who got dementia eval | 1) Follow-up rate: 80j% of survivors participated in evaluation; non-participants had lower education and moe missing data for one of the mid-life exams 2) Important baseline differences: high midlife sbp ore associated with with more stroke, dementia (not ad), and vascular dementia. High midlife dbp associated with more stroke. Men with low and nl baseline pressure 1.5 yrs younger than others. 3) Outcome of interest #1 Analysis stratified by h/o treatment or no treatment with anti-hypertensive medication. Dementia cases = 197; AD=118 Among untreated, high DBP (OR 4.47 (95% CI 1.53 to 13.09), borderline DBP (OR 3.49, 95% CI 1.28 – 9.52) but not mixed DBP (OR 1.33, 95% CI 0.54 to 3.26) associated with AD Among treated, no association between DBP and AD: high DBP (OR 0.14 (95% CI 0.02 to 1.17), borderline DBP (OR 0.71, 95% CI 0.17 – 3.00); mixed DBP (OR 1.35, 95% CI 0.49 to 3.69) Among untreated, no association between SBP and AD: high SBP (OR 1.22 (95% CI 0.37 to 4.04), borderline SBP (OR 1.23, 95% CI 0.63 – 2.43); mixed DBP (OR 0.25, 95% CI 0.05 to 1.14) Among treated, no association between SBP and AD: high SBP (OR 0.65 (95% CI 0.20 to 2.15), borderline SBP (OR 1.03, 95% CI 0.40 – 2.61); mixed DBP (OR 1.03, 95% CI 0.28 to 3.76) 4) Outcome of interest #2 high sbp (1965) and AD (1991–3) 0.56 (0.20–2.15) treated For dementia overall, DBP (high and borderline) associated with dementia in untreated but not treated group. For dementia overall, high SBP but not borderline or mixed associated with dementia in untreated but not treated group. | Comments: Question 1 Dementia eval for those who were over 85 plus those who scored <74 on the casi, considerably lower than the threshold for act. No evaluation for dementia in earlier phases of study. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? No 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Laurin, Masaki, Foley, et al., 2004 HAAS | Geographical location: Oahu, Hawaii Setting: Community Study design: Prospective cohort Number of participants enrolled: 2459 Duration of follow up: Range: 25.7–33.0 yrs Time from risk factor assessment to final cognitive assessment: Range: 25.7–33.0 yrs | Age: Mean (SD): At exam 4: Nondemented: 76.3 (IQR 74.2–79.3) Demented: 78.9 (IQR 76.1–83.3) Sex: [n (%)] Female 0 (0%) Male: 2459 (100%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Men of Japanese ancestry born between 1900 and 1919 who resided on the island of Oahu, Hawaii in 1965 and were participants of the Honolulu Heart Program. Exclusion criteria: NR | Risk factor/exposure 1: beta-carotene, flavonoids, Vit E and C Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Educational level Smoking ETOH use BMI Physical activity Blood pressure Year of birth Total energy intake Cholesterol Hx of cardiovascular disease APOE Supplemental vitamins Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Informant interview?: Yes | 1) Follow-up rate: NR in detail 2) Important baseline differences: Individuals who became demented were older at baseline (p<0.001). No other differences 3) Outcome of interest #1 Beta-carotene – no difference in risk of AD and mixed AD/vasc associated with higher quartiles of intake Vitamin C - – no difference in risk of AD and mixed AD/vasc associated with higher quartiles of intake Vitamin E – 2^nd^ and 4^th^ quartiles only associated with higher risk of AD and mixed AD/vasc (but not the 3^rd^ quartile) 2^nd^ quartile: RR 1.92 (1.16–3.18) 4^th^ quartile: RR 1.78 (1.06–2.98) Flavonoids- no difference in risk of AD associated with higher quartiles of intake No sig trends across quartiles noted for any of the anti-oxidants 4) Outcome of interest #2 Highest group of sum of all antioxidants intake associated with increased risk of AD and AD mixed/vasc dementia compared to lowest summed group. RR=1.82 (1.04–3.21) | Comments: Question 1 Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Partial 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Laurin, Verreault, Lindsay, et al., 2001 Canadian Study of Health and Aging | Geographical location: All 10 Canadian provinces Setting: Community Study design: Prospective cohort AND Nested case-control Number of participants enrolled: 4615 Duration of follow up: 5 years Time from risk factor assessment to final cognitive assessment: 5 years | Age: [underlined: Controls:] Age 65–74: 59.5% Age 75–84: 36.6% Age ≥85: 3.9% [underlined: Dementia:] Age 65–74: 18.6% Age 75–84: 53.7% Age ≥85: 27.7% Sex: Female: [underlined: Controls:] 2351 (60.4%) [underlined: Dementia:] 175 (61.8%) Male: [underlined: Controls:] 1543 (39.6%) [underlined: Dementia:] 109 (38.2%) Race/ethnicity: NR Baseline cognitive status: Normal Non-demented Inclusion criteria: 65 years or older and living in the community in one of 36 selected urban and surrounding rural areas in Canada. Exclusion criteria: Residents of Newfoundland, Dx of CIND or dementia at the first evaluation. | Risk factor/exposure 1: Physical activity Method of assessing risk factor/exposure 1: Self-report Combined 2 questions from the risk factor questionnaire regarding frequency and intensity of exercise for subjects who reported physical activity. Composite physical activity score categorized: 1) “low” = less than weekly 2) “moderate” = weekly 3) “high“= ≥3 times/wk Reference category was no physical activity (subjects who reported no physical activity) Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Family h/o dementia Tobacco use Alcohol use NSAID use Daily living activities Clinical variables Method(s) of assessing cognitive status: Screened with MMSE (screen + if MMSE ≤77). NINCDS-ADRDA DSM-IIIR (baseline) DSM-IV (follow up) Informant interview?: No | 1) Follow-up rate: 4615 of 6434 initially eligible (72%). 442 excluded from the initial 9008 sample because they lived in Newfoundland, 826 had CIND or dementia. Others excluded for death, refusal, lost to follow up. 2) Important baseline differences: NA 3) Outcome of interest #1 285 incident cases of dementia, 436 incident cases of cognitive impairment, and 194 incident cases of AD. 4) Outcome of interest #2 High levels of physical activity were associated with reduced risks of cognitive impairment (age-, sex-, and education-adjusted OR, 0.58; 95% CI, 0.41–0.83), AD (OR, 0.50; 95% CI, 0.28–0.90), and dementia of any type (OR, 0.63; 95% CI, 0.40–0.98). 5) Outcome of interest #3 Authors’ comments: “study showed a significant protective effect of regular physical activity on the risk of CI and dementia, particularly of the AD type” “these associations were mainly in women, with a significant dose- response relationship with decreasing risk with increasing physical activity.” | [Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? No 6) Validated method for ascertaining clinical outcomes: Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Lautenschlager, Cox, Flicker, et al., 2008 FABS Fitness for the Aging Brain Study. | Geographical location: Perth Australia. Setting: Other – Multiple sources. Study design: RCT Test intervention: Physical activity (encouragement to participate in 150 minutes of moderate intensity activity per week) with behavioral intervention to increase adherence. Comparator intervention(s): Usual care. Number of participants enrolled: 311 screened, 170 randomized (141 excluded) Duration of follow up: 18 months. Time from risk factor assessment to final cognitive assessment: 18 months. | Age: Mean (SD): 68.6 (8.7) for the exercise group and 68.7 (8.5) for the control group Sex: [n (%)] Female: 42 (49.4) in the exercise groups 44 (51.8) in the control group. Male: 0 (0%) Race/ethnicity: [n (%)]NR Baseline cognitive status: Non-demented MCI Inclusion criteria: Age >50 yrs Answers yes to the following question: “Do you have any difficulty with your memory?” Exclusion criteria:. 1)Scores lower than 19 of 50 on the Telephone Interview for Cognitive Status–Modified 2)Geriatric Depression Scale-15 score of 6 or higher 3)Drinking more than 4 standard units of alcohol a day 4)chronic mental illness, such as schizophrenia; 5) medical conditions likely to compromise survival, such as metastatic cancer, or render them unable to engage in physical activity, such as severe cardiac failure. 6) severe sensory impairment or lack of fluency in written or spoken English | Risk factor/exposure 1: Physical activity Method of assessing risk factor/exposure 1: Self-report Direct measurement Risk factor/exposure 2: Apoe Method of assessing risk factor/exposure 2: Direct measurement Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Baseline cognitive status (premorbid IQ) Marital Status Adjusted baseline measures of outcome Method(s) of assessing cognitive status: ICD CERAD MMSE Informant interview?: No | 1) Follow-up rate: 138/170 (81.17%) 2) Important baseline differences: None 3) Outcome of interest #1 The effect of the intervention on the entire sample (n=170)- P value for repeated measures ANOVA: Mean change of ADAS-COG scores: Between participants: 0.04 Within participants :0.54 Word List Delayed recall: Between participants: 0.02 Within participants :0.10 No statistically significant difference for the other cognitive, health and quality of life measures. 4) Outcome of interest #2 The effect of the intervention and time on the MCI sample (n=100)- P value for repeated measures ANOVA: Mean change of ADAS-COG scores: Between participants: 0.02 Within participants :0.45 Word List Delayed recall: Between participants: 0.48 Within participants :0.55 No statistically significant difference for the other cognitive, health and quality of life measures. 5) Outcome of interest #3 The effect of the intervention and time on the complete- case analysis sample (n=138)- P value for repeated measures ANOVA: Mean change of ADAS-COG scores: Between participants: 0.0009 Within participants :0.25 Word List Delayed recall: Between participants: 0.01 Within participants :0.45 CDR sum of Boxes: Between participants: 0.003 Within participants :0.64 No statistically significant difference for the other cognitive, health and quality of life measures. | Comments: Good quality RCT with methodology explicitly explained in the manuscript. Quality assessment: For RCTs: 1) Baseline comparability? Yes 2) Valid AD/cognitive outcomes assessment? Yes 3) Subjects/providers blind? No 4) Outcome assessors blind? Yes 5) Incomplete data adequately addressed? Yes 6) Differential dropout rate < 10%? Yes 7) Overall dropout rate < 30%? Yes 8) Conflict of interest reported and insignificant? Yes 9) Randomization adequate? Yes 10) Allocation concealment adequate? Yes
Lee, Buring, Cook, et al., 2006 Women’s Health Study (WHS) | Geographical location: NR Setting: Community Study design: Prospective cohort Number of participants enrolled: 7118 Duration of follow up: 2 yrs Time from risk factor assessment to final cognitive assessment: 2 yrs | Age: Range: ≥ 66 years Sex: Female: 100% Race/ethnicity: NR Baseline cognitive status: Non-demented Inclusion criteria: Women’s Health Study participants 66 yrs or older in 1998. Exclusion criteria: Stroke (n=69) | Risk factor/exposure 1: Education Method of assessing risk factor/exposure 1: Self-report “What is the highest level of education you have completed?” 1) Licensed practical or vocation nurse; 2) 2-year associates degree; 3) 3-year nurse diploma program (reference category); 4) Bachelors in nursing; 5) Masters degree; 6) Doctoral degree. Covariates/potential confounders adjusted for in analyses: BMI, physical activity, high blood pressure, diabetes, postmenopausal hormone use, history of depression, and income Age Smoking Physical activity Alcohol Method(s) of assessing cognitive status: Cognitive function assessed using TICS, a validated telephone battery, plus 4 other cognitive tests: East Boston Memory test (immediate and delayed recalls); Delayed word recall; Category fluency. Summary composite score calculated from all 5 tests. [underlined: Cognitive impairment and decline] defined as worst 10% of test distribution. Informant interview? No | 1) Follow-up rate: 7118 eligible. 408 (5.7%) refused, 396 (5.9%) unreachable. Final sample at baseline: 6314 (88.7%) F/u rate: 5907/6314 (93.5%). 181 (3.1%) refused, 132 (2.3%) lost to f/u, 21 (0.4%) died. 2) Important baseline differences: NA 3) Outcome of interest #1— cognitive impairment Refer to Table 3 in article. 4) Outcome of interest #2— cognitive decline Refer to Table 5 in article. Authors conclusion: “In analysis of cognitive decline, findings were generally consistent with those of initial cognitive function; however, results were somewhat weaker, likely due to the short period over which we measured decline.” Odds ratios of cognitive decline according to educational attainment: RN: 1.0 (ref): LPN/LVN: 1.1 (0.8–1.5) 2-yr AD: 0.9 (0.6–1.4) BA or BS: 1.0 (0.8–1.3) Masters: 1.0 (0.8–1.4) Doctoral: 0.7 (0.4–1.2) After controlling for covariates, there was no statistically significant association between level of education and cognitive decline. | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Lee, Kawachi, Berkman, et al., 2003 Nurses Health Study | Geographical location: U.S. Setting: Community Study design: Prospective cohort Number of participants enrolled: 22,213 contacted. 19,510 (88%) completed baseline interview. 15,594 Duration of follow up: 2 years Time from risk factor assessment to final cognitive assessment: 2 yrs | Age: Mean: 74 yrs. Sex: Female: 19,319 (100%) Male: 0 Race/ethnicity: NR Baseline cognitive status: No exclusion by cognitive function Inclusion criteria: Nurses’ Health Study participants aged 70 yrs or more who were free of diagnosed stroke and had answered the most recent mailed questionnaire. Exclusion criteria: Less than 15 years of education. | Risk factor/exposure 1: Education Method of assessing risk factor/exposure 1: Self-report 3 categories: 1) 3-year RN diploma (77.9%) 2) Bachelor’s degree (16.4%) 3) Master’s/doctoral degree (5.7%) Covariates/potential confounders adjusted for in analyses: Baseline test scores Age Clinical variables Medications Smoking Alcohol BMI SF-36 vitality and mental health scores Method(s) of assessing cognitive status: Cognitive function assessed using TICS, a validated telephone battery, plus 5 other cognitive tests: East Boston Memory test (immediate and delayed recalls); Delayed word recall; Verbal fluency; Digit span backwards test. Global score calculated from all 6 tests. Low scorers defined as <31 points on the TICS. For remaining tests, low score defined as worst 10% of test distribution. Change scores calculated for each test, including global score. Cutpoints defined for each test. Informant interview?: No | 1) Follow-up rate: 22,213 were contacted at baseline. 19,510 (88%) completed the interview (7% refused, and 5% not reached because of inaccurate contact information). 19,319 completed baseline interview. 15,594/19,319 = 80.7% (but f/u was still ongoing at time of this analysis). 13,429 women (69.5%) had complete data for cognitive decline analyses. 2) Important baseline differences: NA 3) Outcome of interest #1— cognitive decline “We found statistically significant trends of decreasing odds of cognitive decline with increasing level of education on all six tests.” [underlined: Global change score OR (95% CI):] 1) RN: 1.0 2) Bachelor’s: 0.80 (0.68,0.94) 3) Master’s/doctorate: 0.65 (0.50, 0.86) 4) Outcome of interest #2— cognitive tests as continuous data “Comparable results; we found statistically significantly less mean decline on five tests for women with advanced graduate degrees, and statistically significant trends of decreasing mean decline with increasing education after multivariate adjustment.” | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Li, Higdon, Kukull, et al., 2004 Adult Changes in Thought (ACT) | Geographical location: Seattle, WA Setting: Community Study design: Prospective cohort Number of participants enrolled: 2581 Duration of follow up: ~ 17 yrs Time from risk factor assessment to final cognitive assessment: Variable | Age: Mean (SD): 75.1 (6.1) Sex: Female: 1409 (59.8%) Male: 947 (40.2%) Race/ethnicity: White 2149 (91.2%) Non-White 206 (8.7%) Missing 1 (0.04%) Baseline cognitive status: Non-demented Inclusion criteria: Group Health Cooperative HMO member; ≥ 65 yo Exclusion criteria: Cognitive Abilities Screening Instrument (CASI) score < 86 | Risk factor/exposure 1: Statin 0 one statin equivalent = 10 mg simvastatin, or 20 mg lovastatin or pravastatin, or 5 mg atorvastatin with use defined as at least 2 consecutive fills within a 6-month period Method of assessing risk factor/exposure 1: Other – pharmacy record Risk factor/exposure 2: Age, sex, medical history, family history Method of assessing risk factor/exposure 2: Self-report Covariates/potential confounders adjusted for in analyses: status Age at entry Yrs of education APOE e4 status Use of other lipid lowering agents Method(s) of assessing cognitive status: Other – CASI screen and if < 86, clinical exam, lab test, neuroimaging and neuropsychological testing; Dx assigned using NINCDS-ADRDA Informant interview?: No | 1) Follow-up rate: 2356 (91.3%) 392 statin users (41 demented; 351 non-demented) 1964 non-statin (271 demented; 1693 non-demented) 168 with AD; 48 possible AD; 96 other dementia (69% AD/possible AD) Unadjusted HR for probable AD (95% CI) No statin 1.0 (ref) Statin 0.90 (0.54 to 1.51) Adjusted HR for probable AD (95% CI) – age, education, APOE-e4 status an use of other lipid lowering agents No statin 1.0 (ref) Statin 0.82 (0.46 to 1.46) No dose response relationship. Adjusted HR analyzed by cumulative equivalent dose (<1,461 s >=1,451 equivalents), duration (< 2 years vs >= 2years) or average daily equivalent dose (<4 vs. >= 4 equivalents/day) showed overlapping confidence intervals. CEQ < 1,461 0.95 (0.46 to 1.97); >= 1,461 (0.73 (0.26 to 2.05) Duration < 2 years 0.91 (0.40 to 2.09); >= 2 years 0.87 (0.31 to 2.47) ADED < 4 0.91 (0.40 to 2.09); >= 4 0.63 (0.21 to 1.91) | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Yes 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Li, Rhew, Shofer, et al., 2007 Adult Changes in Thought (ACT) | Geographical location: Seattle, WA Setting: Community – cohort from health maintenance organization Study design: Prospective cohort Number of participants enrolled: 2581 2356 analyzed Duration of follow up: Baseline (and exposure) 1994-6 then biennially through end of 2004. CASI each follow up; mean f/u duration NR Time from risk factor assessment to final cognitive assessment: up to 10 years | Age: Range: Age 65–69 542 (23%) Age 70–74 730 (31%) Age 75–79 565 (24%) Age 80–84 353 (15%) Age 85+ 166 (7%) Sex: [n (%)] Female: 1414 (60%) Male: 942 (40%) Race/ethnicity: [n (%)] White 2144 (91%) African-Amer 94 (4%) Other 94 (4%) Info missing 24 (1%) Baseline cognitive status: Non-demented Inclusion criteria: Member of community- based, large HMO; age >=65; selected randomly; dementia- free; non-nursing home resident; agree to prticipate (48% of eligibles) and at least one follow-up Exclusion criteria: NR other than above | Risk factor/exposure 1: htn with sbp high ≥ 160, borderline 140–159, dbp high ≥ 90, borderline 80–89. Enrollment bp considered primary exposure Method of assessing risk factor/exposure 1: Direct measurement Covariates/potential confounders adjusted for in analyses: Race (white/nonwhite), Sex, years education, presence of at least one apoE4, (hx cad, cvc, dm, use of antihypertensives), analyses were done but paratmeter estimates not reported for AD, just nonspecific dementia Separate models for three age strata: 65–74, 75–84, older because of significant interaction term for HTN*age Method(s) of assessing cognitive status: NINCDS-ADRDA DSM-IV Informant interview?: No | 1) Follow-up rate: of the 48% of the initial eligible who participated 91% had at least one follow up. 2) Important baseline differences: in hypertensive group, more females, diabetics and use of antihypertensives 3) Outcome of interest #1 Incident dementio =380 (AD = 204) HR for Ad with sbp ≥ 160 compared to <140 age 65–74 1.38 (95% CI 0.71–2.70) age 75–84 0.94 (0.62–1.42) ≥85 0.70(0.25–1.95) HR for Ad with sbp [underlined: 140–159] compared to < 140 age 65–74 1.47 (95% CI 0.80–2.71) age 75–84 0.60 (0.38–0.92) ≥85 0.48 (0.15–1.57) 4) Outcome of interest #2 HR for AD with dbp ≥ 90 compared to dbp < 80 age 65–74 0.82 (95% CI 0.29–2.35) 75–84 0.73 (0.34–1.59) 85+ no cases HR for AD with dbp [underlined: 80–89] compared to dbp < 80 age 65–74 1.71 (95% CI 0.98–2.97) 75–84 0.96 (0.63–1.47) 85+ 1.58 (0.58 – 4.29) Additional analyses that adjusted for additional covariates (hx cad, cvc, dm, use of antihypertensives), analyses were reported to produce little change in the risk estimates | Comments: Question 1 Dementia eval triggered by casi score < 86. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Can’t Tell 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Lindsay, Laurin, Verreault, et al., 2002 Canadian Study of Health and Aging (CSHA) | Geographical location: Eighteen field centers across all Canadian provinces. Setting: Community Study design: Prospective cohort Number of participants enrolled: Community sample:9008 Eligible subjects:7273 Enrolled subjects:6434 Final study sample:4615 Duration of follow up: 5 yrs Time from risk factor assessment to final cognitive assessment: 5 yrs | Age: Case/Control Mean (SD): 81/72.9 Median::87/78 Range: 69–105 yrs/70–100 yrs Sex: Case/control Female: 131 (67.5%)/2239(57.5%) Male: 63(32.5%)/1655(42.5%) Race/ethnicity: NR Baseline cognitive status: Non-demented Inclusion criteria: 65 yrs and older Exclusion criteria: NR | Risk factor/exposure 1: ApoE4 Method of assessing risk factor/exposure 1: Direct measurement Risk factor/exposure 2: High blood pressure Method of assessing risk factor/exposure Self report Direct measurement Risk factor/exposure 3: Depression Method of assessing risk factor/exposure Self report Risk factor/exposure 4: Prior head injury Method of assessing risk factor/exposure Self report Risk factor/exposure 5: Diabetes Method of assessing risk factor/exposure Self report Risk factor/exposure 6: Antihypertensive agents Method of assessing risk factor/exposure Self report Risk factor/exposure 7: Any NSAID use Method of assessing risk factor/exposure Self report Risk factor/exposure 8: Estrogen replacement therapy(ERT) Method of assessing risk factor/exposure 8: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Baseline cognitive status Wine consumption Coffee consumption Medical conditions(arthritis, cancer, thyroid, PUD) Family history AD Vascular disease Tobacco use Method(s) of assessing cognitive status: NINCDS-ADRDA DSM-4^th^ edition Other – NINDS-AIREN Modified Mini-Mental State Exam(3MS)(screening criteria: positive result <78/100) Informant interview?: Yes | 1) Follow-up rate: 4615/6434 (71.7%) participated in follow up study 2) Important baseline differences: NA 3) Outcome of interest #1--APOE Odds ratio(OR) 3.28 (95% CI: 1.98,5.44) 4) Outcome of interest #2—High BP OR 0.88(0.62,1.27) 5) Outcome of interest #3-- Depression OR 1.44(0.84,2.48) 6) Outcome of interest#4—Prior head injury OR 0.87 (0.56,1.36) 7) Outcome of interest#5--Diabetes OR 1.03 (0.58,1.84) 8) Outcome of interest #6— Antihypertensive agents OR 0.91 (0.64,1.30) 9) Outcome of interest#7—Any NSAIDs OR 0.65 (0.44,0.95) 10 )Outcome of interest#8— Estrogen replacement therapy OR 1.37 (0.48,3.95) 11) Years of Education (controlled for age and sex) with ≥13 years as reference. 9–12 yrs: OR 1.37 (95% CI: .91,2.06) 0–8 yrs: OR 1.90 (95% CI: 1.25,2.90) Analysis included 194 AD cases and 3894 cognitively normal controls. Increased risk of AD was associated with ApoE4 while NSAID use was associated with reduced risk of AD. No statistically significant association was found for history of depression, estrogen replacement therapy, high blood pressure, head trauma, antihypertensive use, diabetes. | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Lu, Edland, Teng, et al., 2009 Alzheimer’s Disease Cooperative Study drug trial | Geographical location: 69 ADCS sites in US & Canada Setting: Clinical – participants in the Alzheimer’s Disease Cooperative Study drug trial Study design: RCT (though analyzed as if it were an uncontrolled observational study) Test intervention Vitamin E (2,000 IU) OR Donepezil (10mg) Comparator intervention(s) Matching placebo Number of participants enrolled: 756 208 Depressed 548 Non-depressed Duration of follow up: 3 years Time from risk factor assessment to final cognitive assessment: 3 years | Age: Mean (SD): Depressed 73.11 (7.32) Non-depressed 72.83 (7.31) Range: 55–91 years Sex: [n (%)] Female: Depressed 104 (50%) Non-depressed 241 (44%) Male: Depressed 104 (50%) Non-depressed 307 (56%) Race/ethnicity: [n (%)] White Depressed 193 (93%) Non-depressed 504 (92%) Baseline cognitive status: aMCI Inclusion criteria: Met criteria for aMCI of a presumably degenerative nature (insidious onset, gradual progression), defined as 1) subjective memory complaint corroborated by an informant, 2) insufficient global cognitive and functional impairment to meet National Institute of Neurological and Communicative Disorders and Stroke-Alzheimer’s Disease and Related Disorders Association (NINCDS-ADRDA) criteria for probable AD, 3) Logical Memory (one paragraph) delayed recall score 1.5 SD below education-adjusted normative means, 4) Clinical Dementia Rating (CDR) score of 0.5, and 5) Mini-Mental State Examination (MMSE) score ≥ 24. Exclusion criteria: Score of greater than 12 on the Hamilton Depression Rating Scale (HAM-D) or a modified Hachinski score of >4; h/o significant cerebrovascular disease; CNS infarct, infection, or focal lesions of clinical significance on CT or MRI; medical or psychiatric conditions that could interfere with study participation; pregnancy, lactation, or childbearing potential; or taking vitamins or other supplements (may take stable doses at least 1 month prior to screening of antidepressants lacking significant anticholinergic side effects. | Risk factor/exposure 1: Depression Method of assessing risk factor/exposure 1: Beck Depression Inventory (BDI) Risk factor/exposure 2: APOE genotype Method of assessing risk factor/exposure 2: Direct measurement Covariates/potential confounders adjusted for in analyses: Age Baseline MMSE score APOE genotype Treatment group NYU paragraph delayed recall score Method(s) of assessing cognitive status: NINCDS-ADRDA When the clinical diagnosis of AD was made, all cognitive and functional data were sent to the ADCS Coordinating Center and forwarded to a 5-member central review committee for a consensual diagnosis. Informant interview?: No | 1) Follow-up rate: 756/769 (98%) 2) Important baseline differences: N/A 3) Outcome of interest #1 Impact of risk factor on progression to AD [underlined: BDI score:] HR 1.03 (95% CI: 1.01, 1.06; p=0.022) [underlined: APOE carrier]: HR 2.03 (95% CI: 1.45, 2.83; p<0.0001) | Comments: Question 4 Note: This represents a secondary analysis of an RCT, with data pooled across all three treatment arms (donepezil vs. vitamin E vs. placebo), with adjustment for treatment arm in the Cox model. Quality assessment: For observational studies (although data are from an RCT, they are analyzed as though this were an uncontrolled observational study): 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Luchsinger, Honig, Tang, et al., 2008 WHICAP | Geographical location: Northern Manhattan, NYC, USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 1,128 in parent study; 526 in current analysis Duration of follow up: 5.1 (3.3) years Time from risk factor assessment to final cognitive assessment: 5.1 (3.3) years | Age: Mean (SD): 75.1 (6.4) Sex: [n (%)] Female: 356 (67.7%) Male: 170 (32.3%) Race/ethnicity: [n (%)] AA 31.2% Hispanic 48.3% White 20.5% Baseline cognitive status: Non-demented Inclusion criteria: Medicare recipient selected at random Age >=65 HAMD at baseline At least one f/u Exclusion criteria: Dementia | Risk factor/exposure 1: Depression – Hamilton Depression Rating Scale – 17-item Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level APOE-e4 DM HTN Heart disease Current smoking Stroke Method(s) of assessing cognitive status: NINCDS-ADRDA Informant interview?: No | 1) Follow-up rate: 50.2% >= 4 f/u visits 9.7% 3 f/u visits 17.5% 2 f/u visits 22.6% 1 f/u visit Unknown with 0 visits in the overall cohort 2) Important baseline differences: NR 3) Outcome of interest #1 HAMD = 0, 8 AD cases, HR 1.0 HAMD = 1 to 9, 83 cases, HR 2.3 (1.0 to 5.3) HAMD >9, 23 AD cases, HR 3.0 (1.2 to 7.9) | Comments: Only a convenience sample of overall cohort completed the HAMD and they differed systematically (younger, more DM, hearts disease, stroke) than those not completing the HAMD Quality assessment: For observational studies: 1) Unbiased selection of the cohort: Partial 2) Selection minimizes baseline differences in prognostic factors: Yes 3) Sample size calculated/5% difference: No 4) Adequate description of the cohort: Yes 5) Validated method for ascertaining exposure: Yes 6) Validated method for ascertaining clinical outcomes: Yes 7) Outcome assessment blind to exposure: Can’t Tell 8) Adequate follow-up period: Yes 9) Completeness of follow-up: Can’t Tell 10) Analysis controls for confounding: Yes 11) Analytic methods appropriate: Yes
Luchsinger, Reitz, Honig, et al., 2005 WHICAP | Geographical location: northern Manhatten, NY Setting: ] Community Study design Prospective cohort Number of participants enrolled: 2126 initial screened cohort; 1138 final cohort Duration of follow up: Follow up data were collected ~ every 18 months through ~5 yrs. (6292 person-year follow up) Time from risk factor assessment to final cognitive assessment: Mean 5.5 yrs(SD 3.2 person years) | Age: Mean (SD): 76.2(5.9) Sex: Female: 734(69.8%) Male: 404(40.2%) Race/ethnicity: Black: 377(33.1%) Hispanic: 505(44.4%) White: 256(22.5%) Baseline cognitive status: Non-demented Inclusion criteria: 65 yrs and older, non-demented Exclusion criteria: NR | Risk factor/exposure 1: Diabetes Mellitus Method of assessing risk factor/exposure 1: Self-report Other – Use of specific DM medications Risk factor/exposure 2: Hypertension Method of assessing risk factor/exposure 2: Self-report Risk factor/exposure 3: Tobacco use(current vs past) Method of assessing risk factor/exposure 3: Self report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Baseline cognitive status Vascular disease Lipid values BMI Method(s) of assessing cognitive status: NINCDS-ADRDA Other-Clinical Dementia Rating(>0.5) Informant interview?: No | 1) Follow-up rate: 1012/1138(88.9%) 126 excluded as they were missing APOE4 genotyping. 2) Important baseline differences: NA 3) Outcome of interest #1 At risk, n=36; cases n=11(30.6 %) HR 3.8(1.8,8.2) At risk: n=306; cases n=48(15.7%) HR 1.5(0.9,2.4) 4) Outcome of interest #2— Probable and possible AD (n=246), by risk factor Hazard ratio (95% CI) Diabetes: 3.8 (1.8, 8.2) HTN: 1.5 (0.9, 2.4) Tobacco: 2.2 (1.0, 4.9) 5) Outcome of interest #3 At risk: 41; cases n=9(21.9) HR2.2(1.0,4.9) All data utilized model 2 which adjusted for age, sex, ethnic group, education and APOE4. Sample size 1012 due to 126 missing APOE genotyping All CI :95% Authors’ conclusion: “The risk of AD increased with the number of vascular risk factors, diabetes, HTN, heart disease, and current smoking. We also found that different combinations of risk factors were associated with a high risk of AD. Diabetes and smoking were the strongest risk factors.” | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Luchsinger, Tang, Miller, et al., 2007 WHICAP | Geographical location: Northern Manhattan, NY Setting: Community Study design: Prospective cohort Number of participants enrolled: 965 Duration of follow up: 6.1 (3.3) yr Time from risk factor assessment to final cognitive assessment: 6.1 (3.3) yr | Age: Mean (SD): 75.8 (5.8) Sex: [n (%)] Female: 680 (70.5) Male: 285 (29.5) Race/ethnicity: [n (%)] AA 315 (32.6) White 213 (22.1) Hispanic 437 (45.3) Baseline cognitive status: Non-demented Inclusion criteria: Medicare recipients age ≥65 residing in Northern Manhattan Exclusion criteria: None | Risk factor/exposure 1: Folate, Vit B6 & B12 Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level APOE DM HTN Smoking Heart disease Stroke Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Informant interview?: No | 1) Follow-up rate: 965/1375 (denominator excludes those with dementia, but don’t know how much attrition due to death) 2) Important baseline differences: Ind who dev AD were older, less educated. A higher proportion of Hispanics and a lower proportion of whites dev AD. A higher proportion w/DM, HTN, heart disease and stroke dev AD. 3) Outcome of interest #1 Folate: Higher quartiles of intake were not significantly associated with risk of AD B6: Higher quartiles of intake were not significantly associated with risk of AD B12: Higher quartiles of intake were not significantly associated with risk of AD | Comments: Question 1 The association between folate and AD became significant when also controlled for B 6 & B12 Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Luchingser, Tang, Shea, et al., 2002 WHICAP | Geographical location: Northern Manhattan, NY Setting: Community Study design: Prospective cohort Number of participants enrolled: 980 Duration of follow up: 4 (1.5) Time from risk factor assessment to final cognitive assessment: 4 (1.5) | Age: Mean (SD): 75.3 (5.8) Sex: [n (%)] Female: 657 (67) Male: 323 (33) Race/ethnicity: [n (%)] AA 314 (32) White 245 (25) Hispanic 421 (43) Baseline cognitive status: Non-demented Inclusion criteria: Medicare recipients age ≥65 residing in Northern Manhattan Exclusion criteria: NR | Risk factor/exposure 1: caloric intake, carbohydrates, fats, protein Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level APOE Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Informant interview?: No | 1) Follow-up rate: 980/1192 (1192 includes those lost to follow-up only, not those excluded due to dementia) 2) Important baseline differences: Total calories: highest quartiles older and more education Carbohydrates: Highest quartiles older, less likely to be female, Protein: highest quartiles less education 3) Outcome of interest #1 Total daily calories: quartile 4 assoc with increased risk of AD (HR: 1.48; 1.00–2.19) Carbohydrates: no assoc with AD Fats: no assoc with AD Protein: no assoc with AD 4) Outcome of interest #2 Only APOE 4 positive associated with risk of AD for: Total calories: quartile 4 (HR 2.27 (1.11–4.68) Fats: quartile 4 (HR: 2.31; 1.09–4.89) | Comments: Question 1 Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Luchsinger, Tang, Shea, et al., 2003 WHICAP | Geographical location: Northern Manhattan, NY Setting: Community Study design: Prospective cohort Number of participants enrolled: 980 Duration of follow up: 4 (1.5) Time from risk factor assessment to final cognitive assessment: 4 (1.5) | Age: Mean (SD): Mean (SD): 75.3 (5.8) Sex: [n (%)] Female: 657 (67%) Male: 323 (33%) Race/ethnicity: [n (%)] AA 314 (32) White 245 (25) Hispanic 421 (43) Baseline cognitive status: Non-demented Inclusion criteria: Medicare recipients age ≥65 residing in Northern Manhattan Exclusion criteria: NR | Risk factor/exposure 1: Vit C & E and carotenoids Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Sex Educational level APOE Smoking Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Informant interview?: No | 1) Follow-up rate: 980/1192 (1192 includes those lost to follow-up only, not those excluded due to dementia) 2) Important baseline differences: Vit C & E users had more education Lower proportion of Hispanics were Vit E users 3) Outcome of interest #1 Calorie adjusted intake (no-supplements) Carotenoids: higher intake quartiles no assoc with AD Vit C: higher intake quartiles no assoc with AD Vit E: higher intake quartiles no assoc with AD 4) Outcome of interest #2 Supplemental and dietary intake Vit C: Highest intake quartile no assoc with AD Vit E: Highest intake quartile no assoc with AD | Comments: Question 1 Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Luchsinger, Tang, Shea, et al., 2004 WHICAP | Geographical location: New York City, NY Setting: Community Study design: Prospective cohort Number of participants enrolled: 2126 original subjects 909 sample for this study 679 available for longitudinal analysis Duration of follow up: I can’t tell. Plasma reportedly drawn at baseline. Cog testing done every 18 mos. Reportedly 3,206 person years. Can we assume a mean follow up of 4.7 yrs per person? Time from risk factor assessment to final cognitive assessment: hcy at baseline. Follow ups every 18 mos. | Age: Median: 77 years Sex: Female: 70% Male: 30% Race/ethnicity: Hispanic 52% African American 30% White 18% Baseline cognitive status: Non-demented Inclusion criteria: Medicare recipients Residents of Washington Heights community in NYC Exclusion criteria: Dementia | Risk factor/exposure 1: hcy Method of assessing risk factor/exposure 1: Direct measurement Frozen fasting plasma, doesn’t say how long it was stored. Covariates/potential confounders adjusted for in analyses: age, sex, education, apoE4, stroke Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Informant interview?: No | 1) Follow-up rate: subset who had a follow up and hcy levels seem to have been chosen. 2) Important baseline differences: Subjects with higher hcy were older, more men, less dm, more stroke, more prevalent dementia, more prevalent AD. 3) Outcome of interest #1 When unadjusted those in the highest quartile of hcy as compared to the lowest quartile had hr for ad of 2.0 (1.2 – 3.5). When adjusted for age, sex, education, apoE4, stroke hr was 1.3 (0.8 – 2.3) | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Yes 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Can’t Tell 9) Completeness of follow-up? Partial 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Lytle, Vander Bilt, Pandav, et al., 2004 MoVIES | Geographical location: Southwestern Pennsylvania, USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 1146 Duration of follow up: 2 yrs Time from risk factor assessment to final cognitive assessment: 2 yrs | Age: Mean (SD): 76.8 (5.3) Sex: [n (%)] Female: 722 (63%) Male: 424 (37%) Race/ethnicity: White: 97.7% Non-white: 2.3% Baseline cognitive status: All Inclusion criteria: 65 yrs or older, living in the community, fluent in English, and having at least a 6^th^ grade education. Exclusion criteria: NR | Risk factor/exposure 1: Exercise. Method of assessing risk factor/exposure 1: Self-report Subjects were asked whether they engaged in an exercise program, and, if so, in what type of exercise, exercise equipment used, and freq. and duration of exercise. Aerobic vs. non- aerobic Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Self rating of health Method(s) of assessing cognitive status: Cognitive battery, including the MMSE and a standardized risk factor and outcome assessment questionnaire. Cognitive decline defined as “being in the 90^th^ percentile of decline in this cohort, ie, declining by 3 or more MMSE points during the 2-year interval between assessments.” Informant interview? No | 1) Follow-up rate: Analytical sample 929 Attrition rate due to death 9 – 14% Attrition due to other causes 2.8% 2) Important baseline differences: There was a statistically significant difference in age and sex among the high, low, and no exercise groups at baseline 3) Outcome of interest #1 High exercise level at wave 3 was associated with reduced risk of cognitive decline at wave 4. OR: 0.39, (95%CI 0.19, 0.78) 4) Outcome of interest #2 When high exercise was considered as exercising for more than 5 or more days a week for at least 30 minutes, cognitive decline was negatively associated with high exercise. OR: 0.45, (95%CI 0.22, 0.95) Low exercise also showed a negative association. OR:0.63, (95%CI 0.39, 0.997 Outcome of interest #3 Wave 3 mmse was not associated with future exercise level. This analysis was done to examine both directions of the relationship. | Comments: None Analysis included subjects with baseline cognitive impairment Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? No 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Manly, Schupf, Tang, et al., 2005 WHICAP | Geographical location: Northern Manhattan NY, USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 1362 Duration of follow up: Approximately 4.5 years. Not reported specifically. Time from risk factor assessment to final cognitive assessment: Approximately 4.5 years. Not reported specifically. | Age: Mean (SD): High education: 75.5 (6.2) Low education: 75.9 (5.9) Sex: [n (%)] High education: Female: 67.1% Male: 32.9% Low education: Female: 69.8% Male: 30.2% Race/ethnicity: [n (%)] High education: White 73.6% Low education: White 26.4% Baseline cognitive status: Normal Non-demented Inclusion criteria: English as primary language, self identified as Hispanic, African American or Non-Hispanic White. Exclusion criteria: Stroke, Parkinson’s disease Cognitive or functional impairment at baseline. | Risk factor/exposure 1: Reading Level Method of assessing risk factor/exposure 1: Self-report Direct measurement - Wide Range Achievement Test Version-3 Risk factor/exposure 2: Literacy, education Method of assessing risk factor/exposure 2: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Method(s) of assessing cognitive status: CDR DSM IV Informant interview?: No | 1) Follow-up rate: Of 1362 in current study, 80 were dead, 94 refused and 75 moved out of the area. 111 had missing data. 1002/1113= 90.02% 2) Important baseline differences: High education group was more likely to be White, have more years of education, have higher reading level, and follow up longer. 3) Outcome of interest # After controlling for age, gender, race and education, participants with lower literacy were more likely to have faster decline in cognition. Memory: β= 3.2; p= .002 Executive function: β= 1.0; p= 0.002 Language: β = 0.2; p= .000 | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Partial 5) Validated method for ascertaining exposure? Can’t Tell 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Martin, Szekely, Brandt, et al., 2008 ADAPT | Geographical location: Baltimore, MD Boston, MA Rochester, NY Seattle, WA Sun City, AZ Tampa, FL Setting: Community Study design: RCT Test intervention Celecoxib 200mg 2x/day OR naproxen sodium 220mg 2x/day Comparator intervention(s) placebo Number of participants enrolled: 2528 Duration of follow up: celecoxib 736 dys, naproxen 737 dys, placebo 736 dys Time from risk factor assessment to final cognitive assessment: Up to 3 yrs of annual cognitive assessments | Age: Median: 74 Range: 70–90 Sex: [n (%)] Female: 1160 (45.9%) Male: 1368 (54.1%) Race/ethnicity: [n (%)] White 2452 (97.0%) African American 38 (1.5%) Hispanic 18 (0.7%) Other 20 (0.8%) Baseline cognitive status: Non-demented Inclusion criteria: ≥ 70 yo; have at least 1 first-degree relative with AD-like dementia, score satisfactorily on eligibility test battery for excluding cognitive impairment Exclusion criteria: Regularly use NSAIDS (but aspirin use of 81 mg/day allowed) | Risk factor/exposure 1: RCT with celecoxib, naproxen, placebo Method of assessing risk factor/exposure 1: This is an rct. The nsaid was given to subjects. Covariates/potential confounders adjusted for in analyses: NR Method(s) of assessing cognitive status: change in test scores over time. Informant interview?: No | 1) Follow-up rate: see comments 2) Important baseline differences: none are obvious 3) Outcome of interest #1 Whether an ITT analysis or if censored after drug terminated,, scores of 3MS were significantly lower in both treatment groups than in placebo. 4) Outcome of interest #2 use of naproxen or celecoxib did not improve cognitive function. Weak evidence fro detrimental effect of naproxen. | Comments: Trial terminated early because of celecoxib 41% terminated drug, 19% lost to follow up, naproxen 42% terminated drug, 20% lost to follow up, placebo 38% terminated drug, 21% lost to follow up This group also reports on incident dementia in the other ADAPT publication. For RCTs: 1) Baseline comparability? Yes 2) Valid AD/cognitive outcomes assessment? Yes 3) Subjects/providers blind? Yes 4) Outcome assessors blind? Yes 5) Incomplete data adequately addressed? Partial 6) Differential dropout rate < 10%? Can’t Tell 7) Overall dropout rate < 30%? Yes 8) Conflict of interest reported and insignificant? Yes 9) Randomization adequate? Yes 10) Allocation concealment adequate? Yes
Masaki, Losonczy, Izmirlian, et al., 2000 HAAS | Geographical location: Oahu, Hawaii Setting: Community (some in nursing homes) Study design: Prospective cohort Number of participants enrolled: 3385 Duration of follow up: 3–5 yr Time from risk factor assessment to final cognitive assessment: 3–5 yr for main analyses (sub-group of long term users 11–13 yr) | Age: Mean (SD): Non-demented 73.9 Demented 78.6 Sex: [n (%)] Female 0 (0%) Male: 3385 (100%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Men of Japanese ancestry born between 1900 and 1919 who resided on the island of Oahu, Hawaii in 1965 and were participants of the Honolulu Heart Program. Exclusion criteria: NR | Risk factor/exposure 1: Vit E and C Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Educational level Childhood years spent in Japan APOE Hx of stroke Method(s) of assessing cognitive status: NINCDS-ADRDA DSM CASI Informant interview?: Yes | 1) Follow-up rate: 3385/3682 (denominator excludes those thought to be demented at time of nutrition data collection) 91.93% 2) Important baseline differences: Nondemented were younger, more education, less time during childhood in Japan Some differences (age) reported are at the time of the dementia diagnosis (not really baseline) 3) Outcome of interest #1 No association between AD and vitamin E or C use C w/o E: OR−1.61 (0.67–3.87) E w/o C: OR 0.84 (0.19–3.77) E and C use: OR −1.81 (0.91–3.62) | Comments: Question 1 Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Maxwell, Hicks, Hogan, et al., 2005 CSHA | Geographical location: British Columbia, Prairie Provinces, Ontario, Quebec, Atlantic Provinces, Canada Setting: Community (included residents of institutions) Study design: Prospective cohort Number of participants enrolled: 894 Duration of follow up: Approx 5 yrs Time from risk factor assessment to final cognitive assessment: Approx 5 yrs | Age: Mean (SD): 78.1 (6.8) Sex: [n (%)] Female: 572 (64) Male: 322 (36) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Representative sample of Canadians ≥ 65 yr from the 5 regions noted above For present analyses included only those who completed a clinical exam at baseline and were not demented. Those who completed the clinical exam: ≤ 78 on 3MS, random sample of those scoring >78 on 3MS, those who could not be screened and all institutionalized subjects Exclusion criteria: NR | Risk factor/exposure 1: Vit E and C supplements, including multi-vitamins Method of assessing risk factor/exposure 1: Self-report Medical record – institutionalized subjects Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Blood pressure Baseline cognitive status Institutional residence Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Other – Cog decline= decrease ≥ 10 points on 3MS from Time 1 to Time 2 Informant interview?: No | 1) Follow-up rate: 94/1084 (denominator excludes 698 not followed due to death) 2) Important baseline differences: Vitamin users were older, less likely to have hx of heavy smoking, more likely to lower serum albumin levels 3) Outcome of interest #1 Cognitive decline: Vit E and C and/or multivitamin use assoc with lower risk of cognitive decline (OR −0.51, 0.29-0.-0.90) Any vitamin use assoc with lower risk of cognitive decline (OR −0.57; 0.34–0.93) Vit E alone was not assoc with cognitive decline (OR−0.64 (0.08–5.41) Vit C alone was not assoc with cognitive decline (OR −0.83 (0.29–2.39) 4) Outcome of interest #2 Any vitamin use not assoc with risk of AD (OR−1.00 (0.53–1.87) | Comments: Question 1 & 2 This is on a very select subset of the CSHA sample – those at very high risk of being cognitively impaired, including the institutionalized. Source for risk factor exposures was different for community and institutionalized subjects. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? No 2) Selection minimizes baseline differences in prognostic factors? No 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
McMahon, Green, Skeaff, et al., 2006 (New Zealand Homocysteine) | Geographical location: Dunedin, New Zealand Setting: Community Study design: RCT Test intervention: Folate 1000 micrograms per day Vitamin B12 500 micrograms per day Vitamin B6 10 milligrams per day Comparator intervention(s): Placebo Number of participants enrolled: 465 assessed for eligibility 276 randomized 253 analyzed Duration of follow up: follow ups done at 1 and 2 yrs. Time from risk factor assessment to final cognitive assessment: 2 yrs | Age: Median: 73 years Sex: Female: 65 (52%) in placebo group Female: 47 (37%) in vitamin group Male: 61 (48%) in placebo group Male: 80 (63%) in vitamin group Race/ethnicity: NR Baseline cognitive status: didn’t have “suspected dementia” emsp;all but five had mmse ≥ 26, mean baseline mmse > 29 Inclusion criteria: ≥ 65 years Exclusion criteria: Suspected dementia Taking meds known to interfere with folate metabolism Taking vitamin supplements containing folic acid, B12, or B6 Being treated for depression Diabetic History of stroke or TIAs | Risk factor/exposure 1: hcy Method of assessing risk factor/exposure 1: Direct measurement Fasting plasma, only those >13 μmol/l of hcy were eligible Covariates/potential confounders adjusted for in analyses: Sex, education, baseline cognitive scores. Method(s) of assessing cognitive status: change in test scores Informant interview?: No | 1) Follow-up rate: For purposes of analysis – 91.3% in placebo group, 92.0% in vitamin group. In placebo group, 12 were lost to follow up, and 7% dc’d intervention but stayed in study. In vitamin group, 11 were lost to follow up, and 8 dc’d intervention but stayed in study. 2) Important baseline differences: more women and lower cholesterol in the placebo group. 3) Outcome of interest #1 For the combined testing score, the vitamin group was −0.11 std dev scores WORSE than the placebo group. 4) Outcome of interest #2 1 and 2 yrs change scores were given for each test. The only significant findings in the fully adjusted models was on Trails B for which the mean time to completion was 8% longer in the treatment group (the exponent of the difference between the log- transformed values =1.08; 95% confidence interval1.02–1.14) | Comments: Question 5 rct in cognitive decline Quality assessment: 1) Baseline comparability? Yes 2) Valid AD/cognitive outcomes assessment? Yes 3) Subjects/providers blind? Yes 4) Outcome assessors blind? Yes 5) Incomplete data adequately addressed? Yes 6) Differential dropout rate < 10%? Yes 7) Overall dropout rate < 30%? Yes 8) Conflict of interest reported and insignificant? Yes 9) Randomization adequate? Yes 10) Allocation concealment adequate? Yes
McNeill, Avenell, Campbell, et al., 2007 MAVIS Trial | Geographical location: 6 centers in Northeast Scotland Setting: Clinical – Primary care health centers Study design: RCT Test intervention Supplement containing: 800 μg vitamin A, 60 mg vitamin C, 5 μg vitamin D, 10 mg vitamin E, 1.4 mg thiamin, 1.6 mg riboflavin, 18 mg, niacin, 6 mg pantothenic acid, 2 mg pyridoxine, 1 μg vitamin B12, 200 μg folic acid, 14 mg iron, 150 μg iodine, 0.75 mg copper, 15 mg zinc, and 1 mg manganese Comparator intervention(s) placebo Number of participants enrolled: 910 Duration of follow up: 1 year Time from risk factor assessment to final cognitive assessment: 1 year | Age: Median: Suppl 72 Placebo 71 Range: Suppl 68.0 – 76.0 Placebo 68.0 – 76.0 Sex: [n (%)] Female: 431 (47.3%) Male: Race/ethnicity: [n (%)] NR Baseline cognitive status: NR Authors state: “we did not exclude any participation on the basis of impaired cognitive function, though those with dementia were unlikely to volunteer or would have been excluded by their doctor.” Inclusion criteria: ≥65 yo; had not taken vitamin, mineral, or fish oil supplements within 3 mos of recruitment (1 mo for supplements of water soluble vitamins other than vitamin B12) Exclusion criteria: Did not exclude any participants on basis of impaired cognitive function, though those with dementia were unlikely to volunteer, or would have been excluded by their doctor. | Risk factor/exposure 1: Single tablet containing 11 vitamins and 5 minerals taken daily for 12 months. Method of assessing risk factor/exposure 1: RCT intervention Covariates/potential confounders adjusted for in analyses: NA (RCT) Method(s) of assessing cognitive status: Digit span forward and verbal fluency tests at start and end of intervention period. Informant interview?: No | 1) Follow-up rate: Of the 910 participants, over the course of the 1-year study, 12 died, 77 stopped taking their tablets and 44 were lost to follow-up. Does not appear to be intent-to-treat analysis. Not clear how many participants were included in the final analysis. 2) Important baseline differences: None 3) Outcome of interest #1—Digit span forward No evidence of an effect of supplements 4) Outcome of interest #2—Verbal fluency “No evidence of a beneficial effect on the whole study population but there was weak evidence for a beneficial effect of supplementation in the 2 pre-specified subgroups: 1) age ≥75 (n=290), mean difference 2.8 (95% CI: −0.6, 6.2) 2) increased risk of micronutrient deficiency (n=260), mean difference 2.5 (95% CI: −1.0, 6.1) | Comments: None For RCTs: 1) Baseline comparability? Yes 2) Valid AD/cognitive outcomes assessment? Yes 3) Subjects/providers blind? Yes - Subject; Can’t Tell – Providers 4) Outcome assessors blind? Can’t Tell 5) Incomplete data adequately addressed? Can’t Tell. Analytic approach not described well. 6) Differential dropout rate < 10%? Can’t Tell 7) Overall dropout rate < 30%? Yes 8) Conflict of interest reported and insignificant? Yes 9) Randomization adequate? Yes 10) Allocation concealment adequate? Can’t Tell
Mehta, Ott, Kalmijn, et al., 1999 The Rotterdam Study | Geographical location: Rotterdam, Netherlands Setting: Community Study design: Prospective cohort Number of participants enrolled: 6645 Duration of follow up: Average 2.1 (0.8) years. Time from risk factor assessment to final cognitive assessment: Average 2.1 (0.8) years | Age: Mean (SD): 68.9 (8.6) Sex: [n (%)] Female: 3927 (59.1) Male: 2718 (40.9) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non demented Inclusion criteria: >55 yrs of age Residents of Rotterdam Exclusion criteria: Dementia | Risk factor/exposure 1: Head Trauma Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Sex Education Method(s) of assessing cognitive status: NINCDS-ADRDA and DSM Informant interview?: Yes | 1) Follow-up rate: 6645/7046 94.31% (those not included in analyses were missing TBI info) 2) Important baseline differences: Patient who developed AD were older, less educated and more likely to be women at baseline. 3) Outcome of interest #1 The relative risk of AD for head trauma with loss of consciousness after adjusting for age, sex and education was 0.8; 95% CI 0.4–1.9 4) Outcome of interest #2 RR of AD for number of head traumas: 1 head trauma = 0.8 (0.3–2.0) >1 head trauma = 1.0 (0.1–7.6) 5) Outcome of interest #3 RR of AD for period between head trauma and interview: ≤10 years= 1.4 (0.3–6.3) >10 years= 0.7 (0.2–1.8) 6) Outcome of interest #4: After controlling for age sex and education, APOE did not interact with head trauma in incident AD. | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? No 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? No 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Morris, Beckett, Scherr, et al., 1998 East Boston Study | Geographical location: East Boston, MA Setting: Community Study design: Prospective cohort Number of participants enrolled: 633 Duration of follow up: 4.3 yrs Time from risk factor assessment to final cognitive assessment: 4.3 yrs | Age: Mean (SD): mean range across exposures: 72–75 Sex: [n (%)] Female: range across exposure groups 342–437 (54–69%) Male: 196–291 (31–46%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Stratified sample of residents of East Boston age > 65 yr in 1982–83. In 1985–86 fup, the stratified sample for clinical eval was weighted towards those who were older and had greater cog decline on screening measures Exclusion criteria: NR | Risk factor/exposure 1: Vit E and C supplement use Method of assessing risk factor/exposure 1: Self-report – limited to use in previous 2 wks Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Time to FUP Sample weight Method(s) of assessing cognitive status: NINCDS-ADRDA Informant interview?: No | 1) Follow-up rate: Notes 80% of survivors in selected sample completed f/u 2) Important baseline differences: Vitamin supplement users were more like to have at least some high school education. Vit E users were slightly younger. Multivitamin users more likely to be female and to have more than a H.S. educ 3) Outcome of interest #1 Fewer than expected incident AD cases used Vit C (p=0.04) No difference in expected AD incidence and observed incidence among Vit E users (p=0.23) | Comments: Question 1 No vitamin C or E users among those who became demented – so comparison was based on predicted rate of AD Quality assessment: For observational studies: 1) Unbiased selection of the cohort? No –subsample targeted those at high risk of AD 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes (vitamin use in previous 2 wks) 6) Validated method for ascertaining clinical outcomes? Partial. No informant report. 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes. Ok (new stratified sample at fup) 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate?: Partial (used predicted incidence of AD rather than comparing observed incidence in two exposure groups)
Morris, Evans, Bienias, et al., 2004a CHAP | Geographical location: Chicago, IL Setting: Community Study design: Prospective cohort Number of participants enrolled: 3718 for cognitive decline 815 for incident AD Duration of follow up: Mean 3.9 yrs (for AD analyses) Says Median 5.5 yrs in abstract (appears to be cognitive decline analyses) Time from risk factor assessment to final cognitive assessment: 1041 - 2.7 yrs 3718 – 4.3 yr (these are estimates based on info in other papers) | Age: For AD sample (815): Mean ranged from 71–73.2 across niacin exposure groups Sex: [n (%)] NR in a format that is useful Race/ethnicity: [n (%)] NR in a format that is useful Baseline cognitive status: Non-demented Inclusion criteria: Residents of three geographically contiguous neighborhoods on southside of Chicago. Aged ≥65 yrs Exclusion criteria: NR | Risk factor/exposure 1: Niacin Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level APOE Time interval between assessments Sample weights Vit E Vit C Beta-carotene Multiple vitamin use DM HTN Smoking ETOH use Stroke Heart disease folate Method(s) of assessing cognitive status: NINCDS-ADRDA Other: Cognitive decline on standardized composite measure from all tests-baseline performance incorporated into composite measure Informant interview?: Yes –says informant interviews for the cognitively impaired, but this differs from all other descriptions of this study | 1) Follow-up rate: Difficult to get appropriate numbers 842/1249 new stratified random sample (authors reported 73.95% of survivors completed fup) 4324/6158 completed diet info and 2 cognitive time points (authors reported was 87% of surviving members)- some excluded from group because of invalid diet data 2) Important baseline differences: Lowest quintile of total niacin intake and niacin food intake compared to higher quintiles: higher percent of females, blacks, ind w/stroke, and ind with low food intake of Vit E Lowest quintile of total niacin intake more likely to have APOE e4 allele Highest quintile of both total and food intake of niacin had higher prevalence of DM 3) Outcome of interest #1 Higher quintiles of total Niacin from supplements (p=0.04), from food (p=0.006), from tryptophan (p=0.03) and from niacin equivalents (p=0.01) associated with reduced risk of AD 4) Outcome of interest #2 Food intake of niacin had a linear effect on cognitive decline, but in fully adjusted model did not reach significance (p=0.12). When those with stroke or MI (p=0.002) or low cognitive scores (p=0.03) were excluded there was an sig linear association. | Comments: Reports continuous outcome for cog decline; also mentions categorical outcome but no results provided Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Morris, Evans, Bienias, et al., 2003a CHAP | Geographical location: Chicago, IL Setting: Community Study design: Prospective cohort Number of participants enrolled: 815 Duration of follow up: Mean 3.9 yrs Time from risk factor assessment to final cognitive assessment: Mean 2.3 yr | Age: Range: 65–94 Sex: [n (%)] Female: 497 (61%) Male: 318 (39%) Race/ethnicity: [n (%)] AA: 424 (52%) White and other: 391 (48%) Baseline cognitive status: Non-demented Inclusion criteria: Residents of three geographically contiguous neighborhoods on southside of Chicago. Aged ≥65 yrs Exclusion criteria: NR | Risk factor/exposure 1: fat intake Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level APOE Method(s) of assessing cognitive status: NINCDS-ADRDA Informant interview?: Yes –says informant interviews for the cognitively impaired, but this differs from all other descriptions of this study | 1) Follow-up rate: reported that 75.6% of surviving stratified sample participated (n = 842) then 815/842 had complete diet info 2) Important baseline differences: Higher % of women and vit C users in lowest quintile of intake for both saturated and w-6 polyunsaturated fat Black more likely to be in lowest quintile of saturated fat intake and highest quintile of w-6 polyunsaturated fat intake Ind with APOE e4 mose likely to be in the lowest quintile of saturated fat intake 3) Outcome of interest #1 Saturated fat: highest quintile associated w/increased risk of AD: RR −2.2 (1.1–4.7) Trans-unsaturated fat: Quintiles 2–5 higher risk of AD, but only quintiles 2 (2.4 ;1.1–5.3) and 3 (2.9; 1.2–7.2) significant w-6 polyunsaturated fat: Quintile 5 had lower risk of AD (0.3; 0.1–0.8) Monounsaturated fat, total fat and dietary cholesterol not associated with AD Animal fat and vegetable fat not associated with AD in multivariable models. But when vegetable fat controlled for other dietary fat, there was a linear trend (p = 0.002) for protection against AD (although the RR for ind quintiles was not significant) | Comments: Question 1 Used multivariable model w/o adjustment for other dietary fat Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Morris, Evans, Bienias, et al., 2002a CHAP | Geographical location: Chicago, Illinois Setting: Community Study design: Prospective cohort Number of participants enrolled: 815 Duration of follow up: 3.9 yrs Time from risk factor assessment to final cognitive assessment: 2.3 yrs | Age: Mean (SD): 73.3 (9.7) Sex: [n (%)] Female: 505 (62) Male: 310 (38) Race/ethnicity: [n (%)] AA: 419 (51.4) White and other:396 (48.6) Baseline cognitive status: Non-demented Inclusion criteria: Residents of three geographically contiguous neighborhoods on southside of Chicago. Aged ≥65 yrs Exclusion criteria: None | Risk factor/exposure 1: Antioxidant-vitamin C, E, beta-carotene Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level APOE Time interval to fup Method(s) of assessing cognitive status: NINCDS-ADRDA Informant interview?: Yes –says informant interviews for the cognitively impaired, but this differs from all other descriptions of this study | 1) Follow-up rate: reported that 75.6% of surviving stratified sample participated (n = 842) then 815/842 had complete diet info 2) Important baseline differences: For each antioxidant, ind in the upper quintiles to total intake were more likely to be white, had more education, had higherh intake of other antioxidants than ind in lower quintiles Ind with high food intake of Vit E tended to be men and to have a higher intake of fat and beta carotene, and a lower intake of Vit C Ind with high food intake of Vit C tended to be female and to have a lower intake of Vit E and total fat Ind in lowest quintile of beta-carotene intake more likely to be black and have an APOE e4 allele compared to upper quintiles 3) Outcome of interest #1 Vit E: Food intake only (not food and supplement): highest quintile associated with lower risk of AD (RR −0.30;0.10–0.92); trend for all quintiles p = 0.05 Food and supplements – not significant Vit C: Intake of food only – overall not sig assoc with AD. Trends do not approach significance. Quintile 4 only is associated with reduced risk of AD (RR−0.37; 0.17–0.82) Intake of food and supplements not significant Beta-carotene – neither intake of food only or food plus supplements were significantly assoc with AD 4) Outcome of interest #2 Vit E intake from food: APOE e4 negatives had reduced incidence of AD among Quintiles 3, 4, and 5 (Quintile 5 –RR−0.17; 0.06–0.47) In APOE e4 positives, Vit E not protective against AD. | Comments: Question 1 In description of one sub-analysis – noted that 96 people had diet info collected within 1 yr of f/u assessment – vit E food intake result became non-significant (CI: 0.11–1.02) Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Morris, Evans, Bienias, et al., 2003b CHAP | Geographical location: Chicago, Illinois Setting: Community Study design: Prospective cohort Number of participants enrolled: 815 Duration of follow up: 3.9 yrs Time from risk factor assessment to final cognitive assessment: 2.3 yrs | Age: Range: 65–94 Sex: [n (%)] Female: 497(61) Male: 318 (39) Race/ethnicity: [n (%)] AA 505 (62) White 310 (38) Baseline cognitive status: Non-demented Inclusion criteria: Residents of three geographically contiguous neighborhoods on southside of Chicago. Aged ≥65 yrs Exclusion criteria: NR | Risk factor/exposure 1: fish and n-3 fatty acids, DHA, EPA, linolenic Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level APOE Time interval to fup Method(s) of assessing cognitive status: NINCDS-ADRDA Informant interview?: Yes –says informant interviews for the cognitively impaired, but this differs from all other descriptions of this study | 1) Follow-up rate: reported that 75.6% of surviving stratified sample participated (n = 842) then 815/842 had complete diet info 2) Important baseline differences: Compared to lowest quintile of n-3 polyunsaturated fat intake, those in highest quintile group were more likely to be male, to have more education, to have a hx of HTN, and to have lower consumption of Vit E and all types of fat 3) Outcome of interest #1 Compared to ind who never ate fish, those who did eat fish had lower risk of AD (RR for ≥ 2/wk fish: 0.4 (0.2–0.9). Trend p =0.07 4) Outcome of interest #2 N-3 fatty acid: highest quintile associated with reduced risk of AD (RR=0.4;0.1–0.9); trend p = 0.01 DHA: two highest quintiles associated with reduced risk of AD (RR for highest quintile=0.03; 0.1–0.9); trend p = 0.02 EPA intake not associated with AD risk Linolenic intake not associated with AD risk | Comments: Question 1 Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Morris, Evans, Bienias, et al., 2005 CHAP | Geographical location: Chicago, Illinois Setting: Community Study design: Prospective cohort Number of participants enrolled: 3718 Duration of follow up: 3718 ind –median 5.5 yrs 1964 ind – median 6.3 yrs Time from risk factor assessment to final cognitive assessment: 3718 ind −4.3 yr 1964 ind – 5.1 yr | Age: Mean (SD):Mean range across quintiles of folate exp: 74.0–74.9 Sex: [n (%)] Female: Mean range of % across quintiles of folate exp: 59–68 Male: Race/ethnicity: [n (%)] Mean range of % across quintiles of folate exp:43–75 Baseline cognitive status: Non-demented Inclusion criteria: Residents of three geographically contiguous neighborhoods on southside of Chicago. Aged ≥65 yrs Exclusion criteria: None | Risk factor/exposure 1: Folate and B12 Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Time interval between assessments Vitamin E Vitamin C Multivitamin Method(s) of assessing cognitive status: Other – Cognitive decline on standardized composite measure from all tests-baseline performance incorporated into composite measure (this was noted in previous article but not in this article) Informant interview?: No | 1) Follow-up rate: 4390/6158 completed diet info and 2 cognitive time points (authors reported was 89% of surviving members)-excluded 677 from group because of invalid diet data (does not add up to 3718) 2) Important baseline differences: High intake total folate had more years education, higher baseline cognitive scores, greater consumption of vitamin E and C; less likely to have heart disease or HTN 3) Outcome of interest #1 Total intake of folate: upper to quintiles declined slightly faster than lowest quintile (p value for 5^th^ quintile =0.002; trend p = <.001) Folate intake from food:higher quintiles generally declined slightly faster than lowest quintiles(p value for 5^th^ quintile = 0.02; trend p = .04) | Comments: Question 2 Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Morris, Evans, Bienias, et al., 2002b CHAP | Geographical location: Chicago, Illinois Setting: Community Study design: Prospective cohort Number of participants enrolled: 2889 Duration of follow up: 3.2 yrs (range 1.8–5.9 yr) Time from risk factor assessment to final cognitive assessment: 1.8 (0.7) yrs | Age: Mean (SD): 73.9 Sex: [n (%)] Female: 1791 (62) Male: 1098 (38) Race/ethnicity: [n (%)] AA: 1594 (55%) White: 1295 (45%) Baseline cognitive status: Non-demented Inclusion criteria: Residents of three geographically contiguous neighborhoods on southside of Chicago. Aged ≥65 yrs Exclusion criteria: None | Risk factor/exposure 1: Vitamin E and C Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Total energy from calories Smoking ETOH use Time between assessments Method(s) of assessing cognitive status: Other – Cognitive decline on standardized composite measure from all tests-baseline performance incorporated into composite measure Informant interview?: No | 1) Follow-up rate: 4376/4983 completed cog screen F/U; total of 1486 excluded because no or invalid diet data, or timing of data collection inappropriate 2) Important baseline differences: Vit E supplement users had more education and higher intake of anti-oxidant nutrients Lowest quintile of Vit E intake from food had higher ETOH use, were more likely to be smokers. Black participants had higher intake of Vit E from food, but were less likely to use either Vit E supplements or multi-vitamins 3) Outcome of interest #1 Vitamin E total intake:highest quintile showed less decline ( p=0.05) used ‘multivariable alone’ model Vitamin C total intake – not associated with cognitive decline 4) Outcome of interest #2 Vitamin E food intake: Highest two quintiles associated with less decline (p <0.05) Vitamin C food intake: not associated with cognitive decline | Comments: Question 2 Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Morris, Evans, Bienias, et al., 2004b CHAP | Geographical location: Chicago, Illinois Setting: Community Study design: Prospective cohort Number of participants enrolled: 2560 Duration of follow up: Median 5.6 yr for 2560 ind Median 6.3 yr for 1397 ind Time from risk factor assessment to final cognitive assessment: 4.6 yr for 2560 ind | Age: Mean (SD): Mean range across fat intake quintiles: 73.7–74.3 Sex: [n (%)] Female: mean % range across fat intake quintiles 46.4–76.0 Male: Race/ethnicity: [n (%)] AA: 1587 (62) White: 973 (38) Baseline cognitive status: Non-demented Inclusion criteria: Residents of three geographically contiguous neighborhoods on southside of Chicago. Aged ≥65 yrs Exclusion criteria: None | Risk factor/exposure 1: fat intake Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Total energy from calories Smoking ETOH use Time between assessments HTN Vitamin C Vitamin E Method(s) of assessing cognitive status: Other – Cognitive decline on standardized composite measure from all tests-baseline performance incorporated into composite measure Informant interview?: No | 1) Follow-up rate: 4398/4930 completed at least one cognitive follow-up; others excluded due to no diet data, invalid diet data, inappropriate timing of diet data collection, or hx of stroke or MI resulting in change of diet 2) Important baseline differences: Ind in top quintile of both saturated and trans-unsaturated fat intake were more likely to be male, to be white, to have higher intake levels of all other types of fat, and higher prevalence of smoking. Those with high intake of saturated fat were more likely to have higher baseline cognitive score and hx of HTN. Those with high intake of trans-unsaturated fat tended to have low consumption of alcohol. 3) Outcome of interest #1 Higher intake of saturated fat (trend p=0.04) and trans-unsaturated fat (trend p = 0.07) were linearly associated with greater decline in cognitive score over 6 yrs. When excluding individuals who changed pattern of fat intake in last 10 years and/or those scoring in lowest 15%, effect became stronger. Total fat, vegetable and animal fat, and cholesterol not associated with cognitive change | Comments: Question 2 Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Morris, Evans, Schneider, et al., 2006 CHAP | Geographical location: Chicago, Illinois Setting: Community Study design: Prospective cohort Number of participants enrolled: 1041 Duration of follow up: Median 3.9 yr Time from risk factor assessment to final cognitive assessment: 2.7 yr | Age: Mean (SD): range of means across folate quintiles: 71.7–73.3 Sex: [n (%)] Female: Male: % range across folate quintiles: 34.4–43.1 Race/ethnicity: [n (%)] AA: % range across folate quintiles: 34.6–68.4 Baseline cognitive status: Non-demented Inclusion criteria: Residents of three geographically contiguous neighborhoods on southside of Chicago. Aged ≥65 yrs Exclusion criteria: None | Risk factor/exposure 1: Vitamins B6 and B12, folate Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: [delete any from the list below that do not apply and add items as needed] Age Race Sex Educational level Period of observation APOE Vitamin E Niacin Method(s) of assessing cognitive status: NINCDS-ADRDA Informant interview?: Yes –says informant interviews for the cognitively impaired, but this differs from all other descriptions of this study | 1) Follow-up rate: Can’t determine from info provided – combined 2 waves of incidence data 2) Important baseline differences: High total intake of Vit B6, B12 and folate were associated with being younger, white, more education, greater participation in cognitive activities, not having an APOE e4 allele, and higher intake of Vit E and niacin. High intake of B-12 was associated with higher intake of saturated fats. 3) Outcome of interest #1 Using nutrient adjusted models comparing highest quintile to lowest quintile: Neither total folate (OR=1.6; 0.5–5.2) or folate from food (1.8; 0.8–4.1) was associated risk of AD. Neither total vitamin B-12 (0.6; 0.2–1.6) or vitamin B-12 from food (1.0; 0.3–2.7) was associated with risk of AD. Neither total vitamin B-6 (0.7; 0.2–2.4) or vitamin B-6 from food (0.7; 0.3–1.4) was associated with risk of AD. | Comments: Question 1 Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Partial 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Can’t Tell 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Morris, Evans, Tangney, et al., 2006a CHAP | Geographical location: Chicago, IL, USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 3718 Duration of follow up: Median 5.5 yrs Time from risk factor assessment to final cognitive assessment: 4.3 yr | Age: Mean (SD): Mean range across copper intake quintiles: 74.0–74.8 Sex: [n (%)] Female: Mean % range across copper intake quintiles: 57.7 – 67.1 Male: Race/ethnicity: [n (%)] AA: Mean % range across copper intake quintiles: 48.5–69.5 Baseline cognitive status: Non-demented Inclusion criteria: Residents of three geographically contiguous neighborhoods on southside of Chicago. Aged ≥65 yrs Exclusion criteria: None | Risk factor/exposure 1: Copper, zinc, iron, saturated and trans fats Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Cognitive activities Physical activities ETOH use Stroke Heart disease HTN DM Vitamin E Vitamin C Niacin Folate Method(s) of assessing cognitive status: Other – Cognitive decline on standardized composite measure from all tests-baseline performance incorporated into composite measure Informant interview?: No | 1) Follow-up rate: Authors note 88% of survivors participated in data collection; additional subjects were excluded because of invalid dietary data 2) Important baseline differences: Ind with high copper intake were more likely to have healthy lifestyle behaviors and higher baseline cognitive scores 3) Outcome of interest #1 Neither total intake or food intake of copper, zinc or iron were associated with cognitive decline 4) Outcome of interest #2 Total copper intake combined with diet high in saturated and trans fat was associated with faster cognitive decline (p<0.001) | Comments: Question 2 Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Morris, Evans, Tangney, et al., 2006b CHAP | Geographical location: Chicago, IL, USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 3,718 Duration of follow up: 3718 ind –median 5.5 yrs 1964 ind – median 6.3 yrs Time from risk factor assessment to final cognitive assessment: 3718 ind −4.3 yr 1964 ind – 5.1 yr | Age: Mean (SD): 73.6 Range: 65–102 Sex: [n (%)] Female: 2305 (62) Male: 1413 (38) Race/ethnicity: [n (%)] AA: 2246 (60.4) White 1472 (39.6) Baseline cognitive status: Non-demented Inclusion criteria: Residents of three geographically contiguous neighborhoods on southside of Chicago. Aged ≥65 yrs Exclusion criteria: None | Risk factor/exposure 1: fruit and vegetable Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Cognitive activities Physical activities ETOH use Method(s) of assessing cognitive status: Other – Cognitive decline on standardized composite measure from all tests-baseline performance incorporated into composite measure Informant interview?: No | 1) Follow-up rate: Authors report 92.2% fup rate at 1^st^ fup and 89.8% fup rate at 2^nd^ fup. Additional ind were excluded because of invalid diet data 2) Important baseline differences: Ind with high intakes of fruits and vegetables were likely to be female, to be white, have more years of education, and higher physical activity level. Ind with high intake of fruit more likely to have a cardiovascular condition. 3) Outcome of interest #1 Higher intake of vegetables associated with less cognitive decline (trend p = 0.04). Higher intake of fruit not associated with rate of cognitive decline (trend p = 0.55) 4) Outcome of interest #2 High intake of green leafy vegetables showed strongest association with reduction in cognitive decline (trend p = 0.03) | Comments: Question 2 Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Morris, Evans, Tangney, et al., 2005 CHAP | Geographical location: Chicago, IL, USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 1041 –AD analyses 3718- cognitive decline analyses Duration of follow up: 1041 – median 3.9 yr 3718 – median 5.5 yr (from other study) Time from risk factor assessment to final cognitive assessment: 1041 – 2.7 yrs 3718 – 4.3 yr (these are estimates based on info in other papers) | Age: Mean (SD): range across quintiles of alpha-tocopherol: 74.1–74.8 Sex: [n (%)] Female: % range across quintiles of alpha-tocopherol: 57.6–68 Male: % range across quintiles of alpha- tocopherol: 32–42.4 Race/ethnicity: [n (%)] AA: % range across quintiles of alpha-tocopherol: 56.6–65.4 Other: % range across quintiles of alpha-tocopherol: 34.6–43.4 Baseline cognitive status: Non-demented Inclusion criteria: Residents of three geographically contiguous neighborhoods on southside of Chicago. Aged ≥65 yrs Exclusion criteria: None | Risk factor/exposure 1: tocopherol forms Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level APOE Cognitive activities Observation interval Saturated fat Trans unsaturated fat DHA Vitamin C Method(s) of assessing cognitive status: NINCDS-ADRDA Other – Cognitive decline on standardized composite measure from all tests-baseline performance incorporated into composite measure Informant interview?: No (Does not say used informant and based on my knowledge of methods did not use informant. But many other of their articles say used Informant for the cognitively impaired). | 1) Follow-up rate: NR in format that is useful. Combined incident cases from multiple waves of data collection. 2) Important baseline differences: Ind with high intake of alpha-tocopherols had more education, higher intake of Vit C and n-3 fatty acid DHA. Ind with high intake of gamma tocopherol had lower intake of Vit C, higher intake of saturated and trans unsaturated fats. 3) Outcome of interest #1 Lower AD risk associated with high intake of: Vit E (RR=0.74; 0.62–0.88) Gamma-tocopherol (RR=0.60; 0.41–0.88) Delta-tocopherol (RR=0.75; 0.58–0.96) Alpha-tocopherol equivalents (RR=0.56; 0.32–0.98) 4) Outcome of interest #2 Slower rate of cognitive decline associated with high intake of: Vit E (p=0.0003) Alpha tocopherol (p=0.01) Gamma-tocopherol (p=0.03) Alpha-tocopherol equivalents (p=0.005) | Comments: Question: Q1, Q2 Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Partial. Food frequency questionnaire 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Morris, Scherr, Hebert, et al., 2001 Boston EPESE | Geographical location: Boston, MA Setting: Community Study design: Prospective cohort Number of participants enrolled: 634 Duration of follow up: bp reported mean of 13.6 years before dx and 4.5 yrs before dx Time from risk factor assessment to final cognitive assessment: NR | Age: Mean (SD): 72.2 Range: ≥ 65 Sex: [n (%)] Female: 402 (63.4%) Male: 232 (36.6%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: ≥ 65 years Participating in the East Boston EPESE study Free of AD at baseline Exclusion criteria: NR | Risk factor/exposure 1: htn Method of assessing risk factor/exposure 1: Self-report Direct measurement Risk factor/exposure 2: antihypertensives Method of assessing risk factor/exposure 2: pill bottle inspection Covariates/potential confounders adjusted for in analyses: Age, Sex Educational level Method(s) of assessing cognitive status: NINCDS-ADRDA Informant interview?: No | 1) Follow-up rate: Of those sampled 97% agreed to participate 426 out of 634 (67%) had blood pressure measurements at the end of 6 years and this was the sample included in the analysis. 2) Important baseline differences: Those with sbp ≥ 160 were older, more likely to have cv dz including htn cva, heart dz, dm 3) Outcome of interest #1 no association between sbp measured 13 yrs before dx OR 1.03/10 mmHg (0.80 – 1.32) 4) Outcome of interest #2 inverse association between sbp measured 4 yrs before dx OR 0.82/10mmHg (0.72 – 0.95) | Comments: Called non demented on basis of memory performance for many subjects. May be adequate. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? No 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Muller, Tang, Schupf, et al., 2007 WHICAP | Geographical location: Northern Manhattan, NY, USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 1,833 Duration of follow up: 4.4 (2.5) yrs Time from risk factor assessment to final cognitive assessment: 4.4 (2.5) yrs | Age: Mean (SD): 76.1 (6.0) Sex: [n (%)] Female: 1234 (67.3) Male: 599 (32.7) Race/ethnicity: [n (%)] Hispanic: 720 (39.3) AA: 565 (30.8) White: 548 (29.9) Baseline cognitive status: Non-demented Inclusion criteria: Two related cohorts drawn from probability samples of Medicare recipients, aged ≥ 65 residing in Northern Manhattan. One of the two cohorts excluded individuals who self-reported prevalent dementia. Current analyses limited to subset with assessment of lipid levels. Exclusion criteria: NR | Risk factor/exposure 1: Metabolic syndrome Method of assessing risk factor/exposure 1: Self-report for diabetes when insulin level not available (or use of diabetes medication) Direct measurement (for insulin, only available on 997 subjects) Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level APOE Smoking Cohort drawn from Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Informant interview?: No | 1) Follow-up rate: 1833/2210 (denominator are those with labs done who were not demented at baseline) 2) Important baseline differences: Those with MS were less educated, smoked more, more likely to be female, more likely to be Hispanic. (Table 2 says the MS were younger and that female was not significant, but the text states differently). 3) Outcome of interest #1 Metabolic syndrome (NCEP-ATPIII criteria) was not associated with increased risk of AD (HR: 0.9; 95% CI: 0.6–1.3) n= 1833 4) Outcome of interest #2 Metabolic syndrome (EGIRI criteria) was not associated with increased risk of AD (HR: 1.2; 95% CI: 0.6–2.5) n= 542 | Comments: Question 1 Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Partial 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Muniz-Terrera, Matthews, Dening, et al., 2009 Cambridge City over 75s Cohort Study | Geographical location: Cambridge, UK Setting: Clinical – Primary Care Practices Study design: Prospective cohort Number of participants enrolled: 2053 Duration of follow up: Three f/u visits at 2, 7, & 9 yrs after baseline assessment Time from risk factor assessment to final cognitive assessment: Average of 2, 7, & 9 yrs | Age: Range: 75–84: 1719 (84%) 85+: 334 (16%) Sex: [n (%)] Female: 1328 (65%0 Male: 725 (35%) Race/ethnicity: NR Baseline cognitive status: Non-demented Inclusion criteria: Age ≥85 in 1985 and registered at one of 6 primary care practices in the Cambridge City area. Exclusion criteria: MMSE <24 on an in-home screening evaluation. | Risk factor/exposure 1: Education (left school before or after the age of 14) Profession (manual or non-manual) Married vs. not ever married Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Profession Marital status Baseline MMSE Method(s) of assessing cognitive status: MMSE as part of a detailed clinical interview. Informant interview?: No | 1) Follow-up rate: 1st f/u: 1161/2053 (57%) 2^nd^ f/u: 647/2053 (32%) 3^rd^ f/u: 304/2053 (15%) 2) Important baseline differences: N/A 3) Outcome of interest #1 Rate of decline of MMSE score over 9 years (SE) Left school prior to age 14: 0.01 (0.05) Non-manual profession: 0.05 (0.06) Married: 0.01 (0.05) (Note: none of the above rates of decline reached statistical significance at the p<0.05 level) | Comments: Question 2 – no cat Dx Quality assessment: For observational studies: 1) Unbiased selection of the cohort? No. Selection criteria among eligible primary care patients not reported. 2) Selection minimizes baseline differences in prognostic factors? Can’t Tell 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? No 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? No (15% response rate for all 3 f/u assessments) 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? No (rate of decline of MMSE score over 9 years, especially given low response rate, may not be the most appropriate analysis)
Ngandu, von Strauss, Helkala, et al., 2007 CAIDE study North Karelia Project FINMONIC A study | Geographical location: Kuopio & Joensuu, Finland Setting: Community Study design: Prospective cohort Number of participants enrolled: 1449 Duration of follow up: Mean 21 yrs (4.9) Time from risk factor assessment to final cognitive assessment: Mean 21 yrs (4.9) | Age: [underlined: Midlife evaluation:] Mean (SD): 50.6 (6.0) [underlined: Late-life evaluation:] Mean (SD): 71.6 (4.1) Sex: Female: 900 (62.1%) Male: 549 (37.9%) Race/ethnicity: NR Baseline cognitive status: NR, but unlikely to be impaired at baseline in midlife Inclusion criteria: Participants of one of 4 separate samples (North Karelia Project and the FINMONICA study). lived in two geographically defined areas. Exclusion criteria: NR | Risk factor/exposure 1: education Method of assessing risk factor/exposure 1: Self-report at midlife evaluation. 3 categories: 1) low (≤5 yrs) 2) medium (6–8 yrs) 3) ≥9 yrs Risk factor/exposure 2: Method of assessing risk factor/exposure 2: Covariates/potential confounders adjusted for in analyses: [underlined: Model 1:] Age Sex F/u time Community of residence SES variables Living arrangement Midlife vascular conditions Midlife physical activity smoking APOE late-life diseases depressive symptoms. Method(s) of assessing cognitive status: Screening with MMSE (screen + = MMSE scores ≤ 24) NINCDS-ADRDA DSM-IV Informant interview?: No | 1) Follow-up rate: 1449/2000 (72.5%) participated in the first phase of re-examination. Exclusions: 40 didn’t come to 2^nd^ evaluation, 21 had missing data on education, for a total analytical sample of 1388 of 2000 (69.4%) 2) Important baseline differences: Those with fewer years of education were older; were more likely to have lower income, were more likely to have occupation with more physical activity, more likely to have higher blood pressure and higher cholesterol, and more likely to have higher BMI 3) Outcome of interest #1 61 incident cases of dementia, of which 48 had AD. Total # of dementia cases increased to 117 when patient records of nonparticipants reviewed (# of additional AD cases from record reviews not reported). It appears results reported were based on the 48 AD. 4) Outcome of interest #2 Education associated with risk of dementia in a dose-dependent manner. With ≤ 5 yrs of education as the reference, [underlined: crude] OR (95% CI): [underlined: AD:] 1) 6–8 yrs of education: OR=0.49 (0.24, 1.00) 2) ≥ 9 yrs: OR=0.15 (0.05, 0.40) Similar adjusted ORs. Authors conclude: none of the covariates were significant in the models, so the effect of education appears to be independent of other risk factors for dementia. 5) Outcome of interest #3—APOE APOE did not modify the association, but the risk of dementia and AD was very low among APOE noncarriers with high education. | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Partial 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? No 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Nickelson, Lufkin, Riggs, et al., 1998 | Geographical location: Rochester, MN & Scottsdale, AZ Setting: Clinical – Mayo Clinics Study design: RCT Test intervention: raloxifene 60 mg or 120 mg Comparator intervention(s): placebo Number of participants enrolled: 143 Duration of follow up: 12 months Time from risk factor assessment to final cognitive assessment: 12 months | Age: Mean (SD): 68.4 Range: 51–76 Sex: [n (%)] Female: 143 (100%) Male: 0 (0%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Not stated, but baseline testing indicates good fct Inclusion criteria: Good health except for osteoporosis, free of any serious acute or chronic medical condition that might affect bone or calcium metabolism, and fully ambulatory. Postmenopausal status confirmed by serum estradiol ≤ 73 pmol/l and follicle stimulating hormone ≥ 30 IU/l in age < 60. Osteoporosis documented by Dx of at least one non-traumatic vertebral fracture and a bone mineral density of the lumbar spine or proximal femur of less than the tenth percentile of normal postmenopausal women. Exclusion criteria: Pts with bone disorders other than osteoporosis, clinically significant menopausal symptoms (hot flashes, sweating, etc.), any history of cancer (except superficial basal or squamous cell carcinoma of the skin) within the previous 5 years, acute or chronic liver disease, history of deep vein thrombosis or cerebral vascular accident, or impaired kidney function were excluded. Also, Tx with estrogen, progestin, calcitonin, androgen, or systemic corticosteroid more recently than 6 months prior to study were grounds for exclusion. | Risk factor/exposure 1: Raloxifene 60 or 120mg vs placebo Method of assessing risk factor/exposure 1: clinical trial pill count Covariates/potential confounders adjusted for in analyses: Age Baseline cognitive status Method(s) of assessing cognitive status: [Other – Memory assessment clinics battery Walter Reed performance assessment battery Informant interview?: No | 1) Follow-up rate: 143 randomized 48 placebo; 48 rlx 60mg and 48 rlx 120mg Followup rate Pl 93.7 vs RLX 60mg 95.8 vs RLX 120mg 93.6 2) Important baseline differences: Mean age was slightly older in the Rlx 60 mg group p 0.028. alcohol consumption 3 drinks/wk was greater in the placebo than 60 or 120 mg rlx (33 vs 15 vs 20%) p .022 3) Outcome of interest #1 Memory assessment clinics battery Walter Reed performance assessment battery At 12 months there were no differences in the MAC or PAB | Comments: Among 10 cognitive measures there were no differences in any measures at 12 months. Quality assessment: For RCTs: 1) Baseline comparability? Yes 2) Valid AD/cognitive outcomes assessment? Yes 3) Subjects/providers blind? Yes 4) Outcome assessors blind? Yes 5) Incomplete data adequately addressed? Partial. Last Observation Carried Forward is suboptimal approach. 6) Differential dropout rate < 10%: No 7) Overall dropout rate < 30%: No 8) Conflict of interest reported and insignificant? Can’t Tell 9) Randomization adequate? Yes 10) Allocation concealment adequate? Can’t Tell
Niti, Yap, Kua, et al., 2009 AND Ng, Niti, Zaw, et al., 2009 Singapore Longitudina \| Aging Study (SLAS) | Geographical location: Southeast region of Singapore Setting: Community Study design: Prospective cohort Number of participants enrolled: 2808 eligible @ baseline (of which 2611 were eligible for f/u) 1487 analyzed Duration of follow up: Mean 1.46 (0.5) Time from risk factor assessment to final cognitive assessment: Mean 1.5 years | Age: Mean (SD): 65.4 (7.0) Sex: [n (%)] Female: 944 (63.5%) Male: 543 (36.5%) Race/ethnicity: [n (%)] Chinese 1487 (100%) Baseline cognitive status: Non-demented Inclusion criteria: Chinese participants in the SLAS cohort. Exclusion criteria: Baseline MMSE score ≤23. | Risk factor/exposure 1: Depressive symptoms. Method of assessing risk factor/exposure 1: Local Chinese version of the 15-item Geriatric Depression Scale (GDS). “Depressed symptoms” defined as GDS ≥15. Risk factor/exposure 2: APOE genotype Method of assessing risk factor/exposure 2: Polymerase chain reaction (PCR) Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Baseline MMSE APOE genotype Length of f/u Vascular risk factors or events Method(s) of assessing cognitive status: MMSE “Cognitive decline” defined as ≥1 point drop in MMSE score from baseline to f/u. Informant interview?: No | 1) Follow-up rate: 1487 of 2611 (57%). 15 unfit to be interviewed, 444 refused, 426 could not be contacted, 53 died. Of the remaining 1673 who completed f/u interviews, 169 were excluded because of cognitive impairment at baseline and 17 excluded because of missing APOE genotype data. 2) Important baseline differences: N/A 3) Outcome of interest #1 Incident cognitive impairment: Overall: n=44/1487 (3.0%) Not depressed: n=35/1329 (2.6%) Depressed: n=9/158 (5.7%) Adjusted odds ratio: 2.29 (95% CI: 1.05, 5.00; p=0.04) 4) Outcome of interest #2 Incident cognitive decline, Adjusted OR (95% CI): GDS ≥5: 0.95 (0.61,1.48) APOE carrier: 1.10 (0.86,1.41) Interaction, GDS ≥5 × APOE status: APOE noncarriers: 0.73 (0.44, 1.21) APOE carriers: 2.89 (1.03, 8.12) | Comments: Question 2 – no cat Dx Same study sample used for both articles. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Partial (57%) 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Niti, Yap, Kua, et al., 2008 Singapore Longitudina \| Aging Study cohort | Geographical location: South East region of Singapore Setting: Community Study design: Prospective cohort Number of participants enrolled: 2611 Duration of follow up: 1–2 years. Median= 1.5 years Time from risk factor assessment to final cognitive assessment: 1–2 years. Median= 1.5 years | Age: Mean (SD): 66.0 (7.3) Sex: [n (%)] Female: 1063 (65%) Male: 572 (35%) Race/ethnicity: [n (%)] Chinese Baseline cognitive status: NR, but analyses were re-run excluding those with MMSE <24 and reportedly results were the same Inclusion criteria: Residents of South East Singapore who consented to participate in study >55 yrs of age Exclusion criteria: NR | Risk factor/exposure 1: Physical, social and productive activity Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Baseline cognitive status APOE Functional status Number of co morbidities Vascular risk factor/events Depression Smoking Alcohol Method(s) of assessing cognitive status: Other – Longitudinal cognitive change on MMSE Informant interview?: No | 1) Follow-up rate: Of 2611, 45 died before follow up. Of the 2566, 1635 were included in analysis – 63.71% 2) Important baseline differences: Thos who were lost to follow up were more likely to be men, have lower MMSE scores and lower scores on physical, social as well as productive activity. After categorizing baseline level of leisure activities into tertiles, the trend statistic was significant for those with fewer leisure activities to older, have lower MMSE score, less likely to be female, more likely to have ≤ 6 yrs education, have more comorbid conditions, have more vascular risk factors/events, more likely to be depressed, and more likely to currently smoke. 3) Outcome of interest #1 Compared to those who had low leisure activity levels the odds of cognitive decline among those with high levels of leisure activity was OR = 0.62 (0.46–0.84) and those who had medium leisure activity was OR = 0.60 (0.45 – 0.79) 4) Outcome of interest #2 Among those who had MMSE ≥ 24, Compared to those who had low leisure activity levels the odds of cognitive decline for those with high levels of leisure activity was OR = 0.62 (0.46–0.85) and those who had medium leisure activity was OR = 0.61(0.46 – 0.72) 5) Outcome of interest #3 Compared to those who did not engage in any productive activity, those who engaged in at least one productive activity had lower cognitive decline OR = 0.36 (0.20–0.65) In the total sample, participation in at least one social or physical activity was not associated with dementia. However, in the APOE carriers, those who participated in at least one physical activity (OR=0.34; 95% CI: 0.17–0.68) or at least one social activity (OR=0.40; CI: 0.16–0.99) were less likely to become demented. | Comments: Question 2 – no cat Dx Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes (Response to the survey based methods was more than 75%) 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Partial 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? No 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Okereke, Kang, Cook, et al., 2008 Physician’s Health Study and Women’s Health Study | Geographical location: Throughout the US Setting: Community Study design: RCTs – this is secondary analyses in two separate RCTs. The one RCT was to examine prevention of CVD, cancer and age- related eye disease with vitamin supplements. The other RCT was to examine prevention of CVD and cancer using vitamin E. Number of participants enrolled: PHSII- 5209 WHS-5199 Duration of follow up: PHSII-mean 2 yrs WHS- mean 4 yrs Time from risk factor assessment to final cognitive assessment: PHSII-mean 2 yrs WHS- mean 4 yrs | Age: Mean (SD): PHSII: DM = 74.3, No DM = 74.1 (total cross- sectional sample) WHS: DM=71.5, No DM=71.9 (total cross- sectional sample) Sex: [n (%)] Male and female samples from different source studies, so they were analyzed separately. Percentage of each does not seem relevant here. Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented (ind were included as long as they were able to complete the telephone cognitive measures, so may have included some demented) Inclusion criteria: Participants in the PHSII or WHS and ≥ 65 yr old Exclusion criteria: Ind with onset of DM prior to age 25 | Risk factor/exposure 1: Diabetes Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Educational level Baseline cognitive status BMI HTN Cholesterol Smoking ETOH use HRT Physical activity Depression history Observation time Method(s) of assessing cognitive status: Other – difference in standardized test scores from baseline to fup Informant interview?: No | 1) Follow-up rate: PHSII-5209/5907; WHS – 5199/6326 2) Important baseline differences: Men and women with DM were more likely to have HTN, high cholesterol, be overweight or obese, more sedentary, have low ETOH consumption, and lower baseline cognitive scores. Women with DM were less likely to take HRT. 3) Outcome of interest #1 Men with DM showed greater cognitive decline than men w/o diabetes on the TICS (−0.37; −0.64-- .09), global cognitive score (−0.07; −0.13–0.00, ns) and verbal memory ( −0.07 ( −.014 to 0.01, ns) 4) Outcome of interest #2 Women with DM showed greater cognitive decline than women w/o diabetes on the TICS ( −0.47; −0.71to −0.22), global cognitive score (−0.09; −0.15 to −0.04) and verbal memory (−0.09 (−.015 to −0.02) 5) Outcome of interest #3 There was a dose response effect with duration of diabetes for both men and women for the TICS and global memory score and for the verbal memory score in men | Comments: Question 2 Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Packard, Westendorp, Stott, et al., 2007 PROSPER study | Geographical location: Scotland, Ireland, The Netherlands Setting: Clinical – Primary care Study design: Observational analysis from an RCT Test intervention: Pravastatin Comparator intervention(s): Placebo Number of participants enrolled: 5804 Duration of follow up: Mean = 3.2 years (range 0.7 to 4.2) Time from risk factor assessment to final cognitive assessment: Mean = 3.2 years | Age: Mean (SD): 75 Range: 70–82 Sex: [n (%)] Female: 3000 (52%) Male: 2804 (48%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Age 70–82 High risk for (≈50%) or known vascular disease (≈50%) Total cholesterol 154 to 347 mg/dl and triglyceride < 231 mg/dl Adhere to study drug of >=75% and <=120% during run-in phase Exclusion criteria: MMSE < 24 Various medical criteria related to safety Alcohol or drug abuse Current lipid-lowering treatment | Risk factor 1: LDL-C; HDL-C Method of assessing risk factor 1: Directly measured twice at baseline in a central laboratory standardized through CDC Covariates/potential confounders adjusted for in analyses: Age, sex, country, education; history of vascular disease, MI, stroke, TIA, smoking, antihypertensive medication, BP, BMI, DM; triglyceride, treatment allocation, apoe e4, and baseline cognitive test scores Method(s) of assessing cognitive status: Other – MMSE, picture-word learning test, Stroop color word test, letter digit coding test Informant interview?: No | Follow-up: 86% of potential visits completed; Treatment adherence: 94% in intervention and control Cognitive decline: Differences between last on- treatment and the second of two baseline measures. Difference in changes scores reported (by LDL-C and HDL-C tertile) No significant difference for any cognitive measure: MMSE, Letter digit codes, Picture word learning test- immediate and delayed recall, Stroop test Activities of daily living and Independent activities of daily living: No significant difference by LDL-C or HDL-C tertile for either outcome Continuous outcome [see instructions above] | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Partial; race not given 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Panza, D’Introno, Colacicco, et al., 2008 Italian longitudinal study on aging | Geographical location: Italy – 8 cities Setting: Community Study design: Prospective cohort Number of participants enrolled: 5632 overall, 2963 in this analytic sample but only 1524 included for incident MCI Duration of follow up: 3.5 years Time from risk factor assessment to final cognitive assessment: 3.5 years | Age: Mean (SD): 71.9 (5.0) Sex: [n (%)] Female: 663 (43.5%) Male: 861 (56.5%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Age 65–84 Randomly selected Completed baseline neuropsychological testing Exclusion criteria: Dementia | Risk factor/exposure 1: Depression Method of assessing risk factor/exposure 1: Direct measurement – geriatric depression scale (GDS) ≥ 10 at baseline Risk factor/exposure 2: Vascular risk factors: coronary artery disease, HTN, diabetes mellitus, stroke Method of assessing risk factor/exposure 2: Self-report Direct measurement (examination and blood values, EKG) Medical record Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Stroke, HTN, DM, smoking, total cholesterol Method(s) of assessing cognitive status: 2-stage assessment using modified Petersen’s criteria (subjective memory complaint not required and allowed for non- cognitive disabilities) Informant interview?: uncertain | 1) Follow-up rate: Unclear 2) Important baseline differences: NR 3) Outcome of interest #1 113 incident cases of MCI. RR for MCI with depressive symptoms (1.25; 0.85–1.84) 4) Outcome of interest #2 Subgroup analysis showed increased risk for MCI among those with depressive symptoms and without CAD, RR 1.5 (1.0–2.3); among those with CAD, RR 0.5 (0.2–1.3). However, this association was no longer significant after adjusting for age, gender, education, stroke, HTN, smoking, DM and total cholesterol. | Comments: Question 2 – yes cat Dx 65% power to detect a RR of 1.25 Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Partial, subset with complete data 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Yes 4) Adequate description of the cohort? Partial, race not given 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Can’t Tell 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Paterniti, Verdier- Taillefer, Dufouil, et al., 2002 EVA Study | Geographical location: Nantes, France Setting: Community Study design: Prospective cohort Number of participants enrolled: 1189 (1003 analyzed) Duration of follow up: 4 years Time from risk factor assessment to final cognitive assessment: 2–4 years | Age: Range: 59–71 years Sex: Female: 429 (42.8%) Male: 574 (57.2%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Mmse>25 Inclusion criteria: 59–71 years old Exclusion criteria: MMSE<26 | Risk factor/exposure 1: Depression (CESD>16 for men; >22 for women) Episodic depression = above threshold at one timepoint Persistent depression = above threshold at >1 timepoint Method of assessing risk factor/exposure 1: Self-report at baseline, 2- and 4-year follow-up Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Alcohol use Tobacco use Psychotropic drug use Six chronic medical conditions Baseline MMSE (outcome #3 only) Method(s) of assessing cognitive status: Other – Cognitive decline= Decline in MMSE >=3 points; Low cognitive function = MMSE <25 at 2- and 4- year follow-up Informant interview?: No | 1) Follow-up rate: 1003/1189 = 84% 2) Important baseline differences: More smokers in depressed group 3) Outcome of interest #1 MMSE decline >=3 points at 4 year f/u (161 cases) CESD> threshold: OR=1.55 (95% CI 0.95 to 2.55) Not depressed = referent Episodic depression: OR=1.22 (95% CI 0.68 to 2.18) Persistent depression: OR=2.10 (95% CI 1.23 to 3.58) 4) Outcome of interest #2 Low cognitive functioning (MMSE< 26 at 2- and 4-year f/u. CESD > threshold: OR=3.22 (95% CI, 1.23 to 8.42) 5) Outcome of interest #3 Change in MMSE (4 year - baseline) CESD below threshold (n-881): Mean change=−0.88 (SE 0.06) CESD above threshold (n=122): Mean change = −1.42 (SE 0.16) | Comments: More subjects with depression at baseline did not complete follow-up Quality assessment: For observational studies: 1) Unbiased selection of the cohort: Partial 2) Selection minimizes baseline differences in prognostic factors: Yes 3) Sample size calculated/5% difference: No 4) Adequate description of the cohort: Yes 5) Validated method for ascertaining exposure: Yes 6) Validated method for ascertaining clinical outcomes: Yes 7) Outcome assessment blind to exposure: Can’t Tell 8) Adequate follow-up period: Yes 9) Completeness of follow-up: Yes. 10) Analysis controls for confounding: Yes 11) Analytic methods appropriate: Yes
Peila, White, Masaki, et al., 2006 Honolulu- Heart Program | Geographical location: Oahu, HI Setting: Community Study design: Prospective cohort Number of participants enrolled: 3734 in HHP cohort; 1294 in this analysis Duration of follow up: midlife bps from 1965–74, latelife bp from 1991–3 Cognitive baseline 1991 follow up 1994 Time from risk factor assessment to final cognitive assessment: Variable: 4 to >12 years | Age: Mean (SD): Hypertensive 77 (0.1) Normotensive 76.3 (0.2) Sex: [n (%)] Female: 0 (0%) Male: 1294 (100%) Race/ethnicity: [n (%)]Japanese-American 1294 (100%) Baseline cognitive status: Non-demented Inclusion criteria: Japanese-American men; born between 1900 – 1919; living in Oahu, HI Specific criteria for this study sample not well specified Exclusion criteria: Subjects with missing data on BP Hypertensive treated at mid-life but not late-life Missing data on duration of anti-HTN treatment | Risk factor/exposure 1: antihypertensives Method of assessing risk factor/exposure 1: Self-report Risk factor/exposure 2: htn Method of assessing risk factor/exposure 2: Direct measurement or self-report of HTN or selsf report of antihypertensive medication Covariates/potential confounders adjusted for in analyses: Age, midlife bmi, smoking, cad, cva, atherosclerosis (using abi), apoE4, education Method(s) of assessing cognitive status: NINCDS-ADRDA DSM-IIR/IV In those screening positive on Cognitive Abilities Screening Instrument Informant interview?: yes for those who were evaluated by screen positive men | 1) Follow-up rate: analysis of 1294 who were normotensive t/o study or hypertensive t/o study. Looks like 1223 had abnl bp or missing bp, 64 had tx early but not late and 10 had missing tx data Adjusted loss to f/u: 66.8% in treated vs. 57.4% in untreated hypertensives 31% seem to have been deaths, refusals, demented but I don’t see a breakdown 2) Important baseline differences: subj with htn were older, had higher bp’s at mid and late life, higher bmi, lower abi, more vasc dz, more apoE4 3) Outcome of interest #1 Incident dementia = 108 (AD – 65; AD/VaD – 19) duration of tx, hr for ad 0–5 yrs 0.62(0.27–1.43) 5–12 yrs 0.54 (0.21–1.36) >12 yrs 0.35 (0.16–0.78) as comopared to never treated hypertensives Untreated normotensives 0.26 (0.10–0.66) 4) Outcome of interest #2 tx > 12 yrs as compared with normotensives 0.82 (0.28–2.38) not specifically ad 5) Outcome of interest #3: Annual decline in CASI score was greater for never treated hypertensives (−1.46) compared to treatment for 5–12 years (−1.14) and normotensives (−1.01) but was not statistically significant compared to 0–5 years treatment (−1.22) or >12 years treatment (−1.08) | Comments: Question 1 for antihypertensives Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Partial 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Partial 6) Validated method for ascertaining clinical outcomes? Partial 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? No 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Petersen, Thomas, Grundman, et al., 2005 | Geographical location: multiple sites throughout the US and Canada Setting: Clinical – 69 ADCS in US and Canada Study design: RCT Test intervention: 2000 IU of vitamin E and multivitamin daily; OR 10 mg of donepezil, and a multivitamin OR a multivitamin daily. Comparator intervention(s): Other arms (donepezil and multi-vit OR multi- vit) Number of participants enrolled: 769 Duration of follow up: 3 years Time from risk factor assessment to final cognitive assessment: 3 years | Age: Mean (SD): 72.9 (7.3) Sex: [n (%)] Female: 352 (46) Male: 417 (54) Race/ethnicity: [n (%)] NR Baseline cognitive status: MCI (amnestic) Inclusion criteria: Had amnestic MCI, impaired memory, a Logical Memory delayed-recall score approximately 1.5 to 2 SD below an education-adjusted norm, a CDR of 0.5, a score of 24 to 30 on MMSE, and between 55 to 90 years old. Exclusion criteria: NR | Risk factor/exposure 1: Vitamin E Method of assessing risk factor/exposure 1: Self report – but RCT so some objective evidence Covariates/potential confounders adjusted for in analyses: Age Baseline cognitive status APOE Method(s) of assessing cognitive status: NINCDS-ADRDA Other – Change on cognitive measures, CDR, Activities of Daily Living Scale; the Global Deterioration Scale Informant interview?: Yes | 1) Follow-up rate: 230 of 769 discontinued during trial – no sig diff between treatment arms 2) Important baseline differences: No significant differences 3) Outcome of interest #1 No difference in rate of progression to AD between vitamin E and placebo groups at any point, either among all patients or among apolipoprotein e4 carriers. (HR =1.02; 95% CI, 0.74 to 1.41; P=0.91). At 36 months, no differences in secondary outcomes between vitamin E and placebo groups | Comments: None Quality assessment: For RCTs: 1) Baseline comparability? Yes 2) Valid AD/cognitive outcomes assessment? Yes 3) Subjects/providers blind? Yes 4) Outcome assessors blind? Yes 5) Incomplete data adequately addressed? Yes 6) Differential dropout rate < 10%? Yes 7) Overall dropout rate < 30%? Yes 8) Conflict of interest reported and insignificant? Yes 9) Randomization adequate? Yes 10) Allocation concealment adequate? Yes
Plassman, Havlik, Steffens, et al., 2000 (WWII Veterans with head injury) | Geographical location: All over US Setting: Other –World War II veterans Study design: Retrospective cohort Number of participants enrolled: 2361 Duration of follow up: Approximately 55 years Time from risk factor assessment to final cognitive assessment: Approximately 55 years. | Age: Mean (SD): 73.05 in the exposed and 72.78 in the unexposed Sex: [n (%)] Female: 0 (0%) Male: 2361 (100%) Race/ethnicity: [n (%)] 95% Caucasian 3.5 % AA 1.5 % Other races Baseline cognitive status: No marked cognitive sequelae for 3 months after head trauma. Inclusion criteria: World War II US Navy or Marine male veterans during 1944 to 1945 who had a head injury that was 1) was documented in the military medical records, 2) occurred during military service, 3) produced loss of consciousness, post- traumatic amnesia, or skull fracture, 4) did not penetrate the dura mater, and 5) did not result in marked cognitive impairment or neurologic sequelae more than 3 months post-trauma. Exclusion criteria: 1) the medical record lacked evidence of head injury, loss of consciousness, posttraumatic amnesia, or hospitalization for head trauma; 2) the only reported head injury was before enlistment; 3) the record documented a penetrating head injury, depressed skull fracture, brain surgery, or severe neurologic sequelae; 4) the individual was female or not in the armed services during 1944 to 1945; 5) the individual died during military service. | Risk factor/exposure 1: Head injury Method of assessing risk factor/exposure 1: Self-report Medical record Risk factor/exposure 2: APOE Method of assessing risk factor/exposure 2: Direct measurement Covariates/potential confounders adjusted for in analyses: Age Educational level APOE Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Informant interview?: Yes | 1) Follow-up rate: Of the 5444 identified to be eligible, 2361 (43.36%) completed the baseline interview. Of this sample, 1776 (75.22%) were included in the analysis. The others were excluded due to medical reasons and other exclusion criteria. 2) Important baseline differences: Among those exposed to head injury, those who agreed to participate had higher cognitive functioning and were more educated than those who refused to participate. 3) Outcome of interest #1 History of head injury increased the risk of AD (hazard ratio [HR] = 2.00, 95% CI = 1.03 to 3.90) After controlling for age, HR remained the same for AD (HR = 2.01, 95%CI = 1.03 to 3.91) 4) Outcome of interest #2 Risk for AD increased with severity of head injury Compared with the group with no head injury, there was increased risk of AD for Moderate head injury: (HR = 2.32,95% CI = 1.04 to 5.17) Severe head injury: (HR = 4.51, 95% CI = 1.77 to 11.47) but not for mild head injury (HR = 0.76, 95% CI = 0.18 to 3.29) 5) Outcome of interest #3 After controlling for head injury and years of education, the HR for AD associated with homozygous e4 was 13.97 (95% CI = 4.64 to 42.01) and for e4 heterozygotes was 1.03 (95% CI = 0.43 to 2.50) when compared with men with no e4 as a reference group | Comments: Objective evidence of head injury gathered from hospital records and long period of follow up make this an important study. Though this was not a community sample, it is not feasible to recruit a sample for TBI in for cohort study from the community. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Partial. Retrospective design may lead to bias. 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes. 8) Adequate follow-up period? Yes 9) Completeness of follow-up? No 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Podewils, Guallar, Kuller, et al. 2005 Cardiovascular Health Cognition Study (CHCS – sub-group of CHS) | Geographical location: Sacramento Co., CA; Washington Co., MD; Forsyth Co., NC; Pittsburgh, PA Setting: Community Study design: Prospective cohort Number of participants enrolled: 3375 Duration of follow up: 5.4 yrs Time from risk factor assessment to final cognitive assessment: 5.4 yrs | Age: Mean (SD): 74.8 (4.9) Sex: Female: 59.1% Male: 40.9% Race/ethnicity: Caucasian: 85% Non-Caucasian: 15% Baseline cognitive status: Non-demented Inclusion criteria: Residing in areas listed above Age ≥65 years Participated in the Cardiovascular Health Cognition Study in 1992–2000 Exclusion criteria: Dementia at baseline | Risk factor/exposure 1: Leisure-time energy expenditure and an activity index reflecting # of different physical activities was calculated.” Method of assessing risk factor/exposure 1: Self-report Proxy report Direct measurement Medical record Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Baseline cognitive status apolipoprotein E genotype (APOE) (e4 or non-e4), magnetic resonance imaging white-matter- grade score (<3 or _3), activities of daily living impairment (<1 or _1), instrumental activities of daily living impairment (<1 or _1), Lubben Social Network Score, and social support score Method(s) of assessing cognitive status: NINCDS-ADRDA DSM ICD Informant interview?: No | 1) Follow-up rate: 3608 included in this study. Outcomes available for 3375. 93%follow up rate. N=3041 for fully adjusted models 2) Important baseline differences: Compared with nonparticipants, CHCS participants were younger, more educated, and less likely to have cardiovascular disease 3) Outcome of interest #1--AD Table 5. Multivariate Hazards Ratio (95% CI) 1) 0–1 activities: 1.0 (referent) 2) 2 activities: 0.73 (0.49, 1.08) 3) 3 activities: 0.85 (0.57, 1.29) 4) ≥4 activities: 0.44 (0.34, 0.88) p-trend 0.03 4) Outcome of interest #2 “We identified an inverse association between physical activity and dementia (and AD) for APOE noncarriers, but found no association for APOE carriers.” | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Posner, Tang, Luchsinger, et al., 2002 Washington Heights- Inwood Columbia Aging Project (WHICAP) | Geographical location: Northern Manhattan, NY Setting: Community Study design: Prospective cohort Number of participants enrolled: 1259 Duration of follow up: every 18 mos up to seven years for cog testing Time from risk factor assessment to final cognitive assessment: Variable, up to 7 years. | Age: Mean (SD): Incident AD 79.3 (6.7 Incident VaD 77.9 (6.2) Free of dementia 75.0 (5.6) Sex: [n (%)] Female: Incident AD 108 (12.4%) Incident VaD 41 (4.7%) Dementia-free 721 (83.1%) Male: Incident AD 49 (12.5%) Incident VaD 15 (3.8%) Dementia-free 322 (82.4%) Race/ethnicity: [n (%)] African-American Incident AD 62 (15.2%) Incident VaD 22 (5.4%) Dementia-free 328 (80.4%) Hispanic Incident AD 71 (12.7%) Incident VaD 25 (4.5%) Dementia-free 458 (81.8%) White Incident AD 23 (8.2%) Incident VaD 9 (3.2%) Dementia-free 249 (88.3%) Other Incident AD 1 (11.1%) Incident VaD 0 (0%) Dementia-free 8 (88.9%) Baseline cognitive status: Non-demented Inclusion criteria: Participant in Washington Heights-Inwood Columbia Aging Project; randomly selected; agreed to participate (1259/2126), no AD @ baseline; Medicare recipient; ≥ 65 yo Exclusion criteria: NR | Risk factor/exposure 1: htn Method of assessing risk factor/exposure 1: Self-report and Direct measurement measured × 3 with dinamap, last reading used, >140 sbp and > 90 dbp considered htn, not clear how self report counted. Covariates/potential confounders adjusted for in analyses: Age Race, Sex, Educational level, dm, heart disease (mi, chf, angina) Method(s) of assessing cognitive status: NINCDS-ADRDA Informant interview?: No | 1) Follow-up rate: 540/1799 (30%) died, refused, or moved; those w/f/u were younger, more likely to be Hispanic, and less likely to have DM or heart disease 2) Important baseline differences: subj with htn had more heart dz, dm and cva and less smoking 3) Outcome of interest #1 Incident AD=157; Incident VaD=56; risk of AD with a history of htn: HR= 0.8 (95% CI, 0.6–1.1) 4) Outcome of interest #2 Treatment of htn did not affect risk estimates for AD: no tx HR= 0.96 (95% CI 0.6 –1.5), tx HR 0.86 (95% Ci 0.6 –1.5) In additional analyses, no additive or synergistic effects were found between HTN and other vascular risk factors and risk of AD. 5) Outcome of interest #3 GEE analysis of composite factors for memory, language, cognition (based on neuropsych testing) showed no association between HTN and cognitive peformance. | Comments: Question 1 Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Partial 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Partial 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Partial 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Potter, Plassman, Helms, et al., 2006 Duke Twins Study | Geographical location: throughout the US Setting: Community Other – Twin Registry Study design: Prospective cohort Number of participants enrolled: 3880 Duration of follow up: 7 years Time from risk factor assessment to final cognitive assessment: 7 years | Age: Mean (SD): 65.83 (2.74) Sex: [n (%)] Female: 0% Male: 100% Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Member of the NAS- NRC Twin Registry of male WWII veterans. Not demented. Both members of twin pair have occupation data and cognitive data. Exclusion criteria: NR | Covariates/potential confounders adjusted for in analyses: Age Educational level Baseline cognitive status Twin pairing Medical conditions Method(s) of assessing cognitive status: Other – Cognitive decline on TICS-m Informant interview?: No –not for this part of the study | 1) Follow-up rate: NR 2) Important baseline differences: NR 3) Outcome of interest #1 Within twin pairs, jobs with higher general intellectual demands were associated with more improvement in cognitive function from baseline to follow-up (p = 0.011) Within twin pairs, jobs with higher physical exertion (p = 0.002) and higher visual attention (p = 0.023) was associated with greater cognitive decline. 4) Outcome of interest #2 Within twin pairs, these occupational factors contributed little to cognitive change compared to the baseline cognitive score, the twin pairing, and education. | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? No, not blind to occupation but would not have known occupational factors 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Can’t Tell 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Price, Stewart, Deary, et al., 2008 Aspirin for Asymptoma tic Atherosclerosis (AAA) Study | Geographical location: Edinburgh, Glasgow, & Lanarkshire, in Central Scotland Setting: Clinical – mailing to general medical practices Study design: RCT Test intervention Daily enteric aspirin 100mg Comparator intervention(s) placebo Number of participants enrolled: 3350 randomized 504 enrolled after cognitive testing 399 in subset at 5 yr f/u Duration of follow up: 5 years Time from risk factor assessment to final cognitive assessment: Final cognitive assessment about 5 yrs post enrollment in RCT | Age: (at randomization) Mean (SD): 62 (7) Range: 50–75 Sex: [n (%)] Female: 2396 (71.6%) Male: 954 (28.4%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Normal Inclusion criteria: > 50 yo; participating in Aspirin for Asymptomatic Atherosclerosis Trial Exclusion criteria: History of MI, angina, PAD, or stroke; if taking aspirin or warfarin; ankle brachial index >0.95 in both legs; severe indigestion; chronic liver or kidney disease; chemotherapy; contraindications to Tx w/ aspirin; an abnormally high or low packed cell volume | Risk factor/exposure 1: RCT asa (100 mg daily) /placebo given Covariates/potential confounders adjusted for in analyses: Age Sex, abi, cholesterol, smoking, Carstairs deprivation category, baseline test results Method(s) of assessing cognitive status: Other – Change in cognitive score over time Informant interview?: No | 1) Follow-up rate: 24.8% of ASA lost, 16.8% of placebo lost 2) Important baseline differences: We don’t have good info on cognitive change subset. 3) Outcome of interest #1 No significant differences in the change in cognitive ability over the five years for any of the individual tests or for the general factor between the treatment groups. | Comments: Can only use the cognitive change subgroup (N=399). Quality assessment: For RCTs: 1) Baseline comparability? Can’t Tell 2) Valid AD/cognitive outcomes assessment? Yes 3) Subjects/providers blind? Yes 4) Outcome assessors blind? Yes 5) Incomplete data adequately addressed? Yes 6) Differential dropout rate < 10%? Partial 7) Overall dropout rate < 30%? Yes 8) Conflict of interest reported and insignificant? Yes 9) Randomization adequate? Yes 10) Allocation concealment adequate? Yes
Prince, Cullen, and Mann, 1994 MRC study | Geographical location: 226 general practices in UK Setting: Community (drawn from general practice lists) Study design: Nested case-control Test intervention: Atenolol 50mg daily (n=640) or hctz 25mg + amiloride 2.5mg daily (n=633) adjusted to BP target range Comparator intervention(s): Placebo (n=1311) Number of participants enrolled: 2651 in cognitive substudy; 453 included in this analysis Duration of follow up: 54 months (4.5 years) Time from risk factor assessment to final cognitive assessment: 4.5 years | Age: Range: 65–74 years Sex: NR Race/ethnicity: NR Baseline cognitive status: [delete all that do not apply] Non-demented, but only routine clinical assessment Inclusion criteria: SBP 160–209 and mean DBP < 115 mmg Hg Age 65–74 Exclusion criteria: Taking anti-HTN med CHF, angina, DM, asthma or other serious disease MI or CVA w/in 3 months | Risk factor/exposure 1: Area of residence from birth to 15 years (rural/urban) 2. Maternal age>34; paternal age >37 3. Paternal social class 4. Education <10 years 5. Current smoking 6. Elevated depression score Method of assessing risk factor/exposure 1: Self-report + Proxy report Risk factor/exposure 2: Cholesterol >7.2mmol 2. BMI 3. SBP >190 at baseline 4. IQ (NART score) Method of assessing risk factor/exposure 2: Direct measurement Covariates/potential confounders adjusted for in analyses: Age Sex IQ FH of dementia Area of residence Method(s) of assessing cognitive status: 2-stage screening - NINCDS-ADRDA DSM-IIIR Other – Paired associated learning test (PALT) decliner = >=16 at baseline and <16 at f/u Informant interview?: Yes- for a small subset | 1) Follow-up rate: 73% during trial; only 67% of the PALT decliners completed further cognitive evaluation 2) Important baseline differences: NR 3) Outcome of interest #1 223 PALT decliners; Within PALT decliners, Incident dementia = 50 (AD=31); AD Current rural residence OR 0.28 (0.08–0.94) Smoking >=10 cigarettes daily: OR 4.38 (1.47–13.1) Dementia: Adjusted OR showed no significant association for: area of residence from birth to age 15, season of birth, paternal social class, serum cholesterol BMI, systolic HTN, smoking, ecg arrythmia, extreme fall in SBP or DBP 4) Outcome of interest #2 Risk factors for cognitive decline on the PALT Moduretic Rx: OR 2.00 (95% CI 1.17–3.45) Low premobid IQ: OR=2.03 (1.27–3.26) <10 years education: 2.12 (1.20–3.57); no secondary school OR 2.20 (1.25–3.88); no tertiary education OR 2.02 (1.00–4.08) Advanced paternal age: OR 0.49 (0.27–0.91) | Comments: Multiple comparisons – no adjustment Limited power (post-hoc calculations estimate 37–50%) Baseline IQ higher than general population Only 63% of controls were available for additional information on exposures Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Partial 3) Sample size calculated/5% difference? Yes, Post-hoc 4) Adequate description of the cohort? No 5) Validated method for ascertaining exposure? Partial 6) Validated method for ascertaining clinical outcomes? Partial 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Not Applicable 10) Analysis controls for confounding? Can’t Tell 11) Analytic methods appropriate? Yes
Prince, Rabe- Hesketh, and Brennan, 1998 MRC Treatment Trial of Hypertensi on in Older Adults | Geographical location: United Kingdom Setting: Clinical – UK general practices Study design: Nested case-control analysis in sample recruited for RCT of anti-hypertensive medication treatment Number of participants enrolled: 2651 Duration of follow up: 8 years for trial, Cognitive substudy: baseline 1983–4, nart at bl, palt and trails A Time from risk factor assessment to final cognitive assessment: baseline, months 1, 9, 21, 54 | Age: Mean (SD): 70 years Range: 65–74 years Sex: Female: 58% Male: 42% Race/ethnicity: [n (%)] NR Baseline cognitive status: these are trial participants so theoretically could give consent. No baseline cognitive requirements. Mean age 70. Inclusion criteria: Participation in the MRC treatment trial of hypertension in older adults Exclusion criteria: Serious cardiovascular, cerebrovascular, or other intercurrent illnesses | Risk factor/exposure 1: nsaids Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Entry PALT score, entry depression score, NART score Method(s) of assessing cognitive status: change in PALT scores. Informant interview?: No | 1) Follow-up rate: 62% had four data pts, 88% had 3 data pts, 2) Important baseline differences: nsaid users: more female, sl older, higher bmi, more depressive symptoms. More antidepressants, more benzos. Less likely to smoke. 3) Outcome of interest #1 They say there is a slight protective effect until age 74, but I am having trouble understanding their data. | Comments: reanalysis of a htn treatment trial: beta blocker, thiazide or placebo. All hypertensive and untreated at entry. Trial participants but no baseline cog testing. Mean age 70. It doesn’t seem that PALT over time is sufficient to determine cog decline. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? No 2) Selection minimizes baseline differences in prognostic factors? No 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Partial 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? No 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Not Applicable 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Prince, Bird, Blizard, et al., 1996 MRC Trial | Geographical location: 226 UK locations Setting: Clinical – drawn from GP registries Study design: RCT Test intervention: Atenolol 50mg daily (n=640) or hctz 25mg + amiloride 2.5mg daily (n=633) adjusted to BP target range Comparator intervention: Placebo (n=1311) Number of participants enrolled: 4396 overall 2584 in cognitive substudy Duration of follow up: Mean = 5.8 years Time from risk factor assessment to final cognitive assessment: 5.8 years | Age: Range: 65–74 years Sex: Female: 58% Male: 42% Race/ethnicity: NR Baseline cognitive status: Normal Non-demented MCI CIND AAMI AACD Inclusion criteria: SBP 160–209 and mean DBP < 115 mmg Hg Age 65–74 Exclusion criteria: Taking anti-HTN med CHF, angina, DM, asthma or other serious disease MI or CVA w/in 3 months | Covariates/potential confounders adjusted for in analyses: Age Sex Baseline cognitive status Method(s) of assessing cognitive status: Other – Paired associate learning test, Trails A,– administered at baseline, 1, 9, 21, and 54 months Informant interview?: No | 1) Follow-up rate: 88% completed at least 3 of the 5 f/u assessments 2) Important baseline differences: No 3) Outcome of interest #1 No signficiant difference in PALT or Trails A between groups Secondary “per-protocol” analysis did not show any significant difference on the PALT or Trails A between groups | Comments: Mean fall in BP was 39.3 for diuretic, 31.5 for b-blocker and 14.7 for placebo. Quality assessment: For RCTs: 1) Baseline comparability? Yes 2) Valid AD/cognitive outcomes assessment? Yes 3) Subjects/providers blind? Partial (subjects blind/providers not blind) 4) Outcome assessors blind? Can’t Tell 5) Incomplete data adequately addressed? Yes 6) Differential dropout rate < 10%? Yes 7) Overall dropout rate < 30%? Yes 8) Conflict of interest reported and insignificant? Yes 9) Randomization adequate? Yes 10) Allocation concealment adequate? Can’t Tell
Qiu, Winblad, Fastbom, et al., 2003 AND Guo, Fratiglioni, Viitanen, et al., 2001 Kungsholmen Project | Geographical location: Stockholm, Sweden Setting: Community Study design: Prospective cohort Number of participants enrolled: 1473 in overall cohort; 966 in this analysis Duration of follow up: Median 5.7 years Time from risk factor assessment to final cognitive assessment: Median 5.7 years (range 0.1 to 8.2 ) | Age: Range: ≥ 75 years Sex: [n (%)] Female: 727 (75%) Male: 239 (25%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Age >=75 y.o Resident of Kungsholmen district APOE and baseline BP data available Exclusion criteria: Dementia | Risk factor/exposure 1: Anti-hypertensive at baseline Method of assessing risk factor/exposure 1: Self-report Direct measurement- bottles or prescriptions when available Risk factor/exposure 2: Apo# E4; HTN at baseline Method of assessing risk factor/exposure 2: Direct measurement Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Baseline cognitive status Vascular disease SBP, DBP and antihtn drug use Method(s) of assessing cognitive status: 2 physicians independently made a preliminary diagnosis and 3^rd^ opinion used for disagreements; for deceased subjects, 2 MDs made diagnosis after reviewing medical records and death certificates NINCDS-ADRDA like criteria DSM-IIIR Informant interview? No | 1) Follow-up rate: Drop-out was related to increasing age and decreased baseline MMSE 2) Important baseline differences: Yes by APOE status 3) Outcome of interest #1 Incident AD = 204 subjects Relative risk for AD by exposure: Any E4, RR=1.6 (95% CI, 1.2–2.1) SBP <140 (reference) 140–159, RR 1.3 (0.8–2.0) >=160, RR 1.4 (0.9–2.2) DBP <70, RR 1.9 (1.2–3.0) 70–89, Reference >=90, RR 1.0 (0.7–1.4) Anti-HTN medication, RR 0.6 (0.5–0.9); risk reduction only noted in those with elevated SBP (>=140; RR 0.6, 95% Ci 0.4 to 0.8) or with elevated DBP (>=70, RR = 0.6, 95% CI 0.5–0.9) 4) Outcome of interest #2 Interaction terms: APOE-e4 allele combined with low DBP increased the risk of AD (RR 4.5, 95% CI 2.6–8.0), independent of anti-HTN drug use. Anti-HTN treatment reduced the risk of AD, regardless of APOE-e4 status | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Partially 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Partial 6) Validated method for ascertaining clinical outcomes? Partial 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Can’t Tell 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Ravaglia, Forti, Lucicesare, et al., 2008a Conselice Study of Brain Aging (CSBA) | Geographical location: Conselice municipality, Italy Setting: Community Other – also included institutionalized individuals Study design: Prospective cohort Number of participants enrolled: 749 Duration of follow up: Mean 3.9 (sd = 0.7) years Time from risk factor assessment to final cognitive assessment: Mean 3.9 (sd = 0.7) years | Age: Mean (SD): 73.2 (6.0) Sex: [n (%)] Female: 401 (53.5) Male: 348 (46.5) Race/ethnicity: [n (%)] NR Baseline cognitive status: Normal Inclusion criteria: ≥65 yrs old participant in the CSBA study Exclusion criteria: Individuals with baseline diagnosis of MCI, dementia, or unclassified cognitive status. Individuals with sensory/motor deficits precluding outdoor activity, missing APOE genotype or lacked follow-up info to determine cognitive status | Risk factor/exposure 1: physical activity a) no. of city blocks walked daily, b) no. flights of stairs climbed daily, c) frequency and duration of weekly participation during past year in occupational, recreational and sport activity Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Sex Educational level APOE Cardiovascular disease Hypertension Hyperhomocysteinema Cerebrovascular disease Diabetes COPD Cancer ADL motor impairment Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Other – MCI defined as MMSE <24, not demented, ≤ 1.5 sd below age/education adjusted norms on any test, independently perform ADL/IADL Informant interview?: Yes | 1) Follow-up rate: 749/865 2) Important baseline differences: NR 3) Outcome of interest #1 54 incident AD cases 86 incident dementia total 4) Outcome of interest #2 None of the categorizations of physical activity was significantly associated with incident AD. Some HRs were above 1.0 and some were less than 1.0 | Comments: Question 1 Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Partial 5) Validated method for ascertaining exposure? Partial 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Ravaglia, Forti, Lucicesare, et al. 2008b Conselice Study of Brain Aging | Geographical location: Conselice, Italy Setting: Community Study design: Prospective cohort Number of participants enrolled: 864 Duration of follow up: years 3.9 (0.5) Time from risk factor assessment to final cognitive assessment: 3.9 (0.5) | Age: Median: NCI-72.3 (5.6) MCI- 78.1 (8.3) Sex: [n (%)] Female:NCI-306 (48.6) MCI- 36 (50) Male: NCI-323 (51.4) MCI- 36 (50) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Age >=65 years old Exclusion criteria: Dementia at baseline or during f/u Major sensory – motor deficits or any psychiatric condition (other than depression) hampering a reliable cognitive assessment. | Risk factor/exposure 1: Depression by GDS- 30 >=10 at baseline 2: Antidepressant use at baseline Method of assessing risk factor/exposure 1: Self-report Risk factor/exposure 1: APOE genotyping Method of assessing risk factor/exposure 1: Direct: PCR Covariates/potential confounders adjusted for in analyses: Age Sex Educational level APOE genotype Framingham stroke risk score HTN Hyperhomocysteinemia Method(s) of assessing cognitive status: 2-stage evaluation with neuropsycho-logical testing Other – MCI: a) age and education adjusted score >= 1.5 SD below reference threshold on any neuropsycholgical testing; b) no need for supervision or external help in ADLs or IADLS; c) absence of DSM-IV criteria for dementia …Subclassified into MCI with objective memory impairment and MCI w/o memory impairment Informant interview?: No | 1) Follow-up rate: 675/864=78% After excluding incident dementia (n=78)or unclassifiable status (n=3), 595 analyzed 2) Important baseline differences: 3) Outcome of interest #1 Incident MCI (155 subjects) GDS >=10: 1.1 (0.7 to 1.9) Antidepressant use at baseline: OR 2.9 (1.3 to 6.6) 4) Outcome of interest #2 Subgroup analyses for MCI with memory impairment (79 subjects) GDS >=10: 1.1 (0.5 to 2.0) Antidepressant use at baseline: OR 2.8 (1.0 to 7.7) Subgroup analyses for MCI without memory impairment (76 subjects) GDS >=10: 1.2 (0.6 to 2.3) Antidepressant use at baseline: OR 3.1 (1.2 to 8.2) A test for interaction between baseline elevated GDS and antidepressant use was significant. Risk of MCI for both compared to no antidepressant/low GDS: OR 12.0 (95% CI 2.8 to 52.1) | Comments: Very low educational status – 85% < 5 years Logistic regression analyses Quality assessment: For observational studies: 1) Unbiased selection of the cohort: Yes 2) Selection minimizes baseline differences in prognostic factors: Yes 3) Sample size calculated/5% difference: No 4) Adequate description of the cohort: Yes 5) Validated method for ascertaining exposure: Yes 6) Validated method for ascertaining clinical outcomes: Yes 7) Outcome assessment blind to exposure: Can’t Tell 8) Adequate follow-up period: Yes 9) Completeness of follow-up: Yes 10) Analysis controls for confounding: Yes 11) Analytic methods appropriate: Yes
Ravaglia, Forti, Maioli, et al., 2005 AND Ravaglia, Forti, Maioli, et al., 2007 Conselice Study of Brain Aging | Geographical location: Conselice, Italy Setting: Community Study design: Prospective cohort Number of participants enrolled: 937 dementia free at baseline Duration of follow up: 3.8 yrs (0.8) Time from risk factor assessment to final cognitive assessment: 3.8 yrs | Age: Mean (SD): 74.6 (7.1) Range: ≥ 65 years Sex: [n (%)] Female: 563 (55%) Male: 453 (45%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Resident of Conselice Age ≥ 65 years as of 01 JAN 1999 Exclusion criteria: NR | Risk factor/exposure 1: hcy Method of assessing risk factor/exposure 1: Direct measurement Fasting plasma, frozen, doesn’t say how long Covariates/potential confounders adjusted for in analyses: age, sex, education, apoE, stroke, creatinine, folate, vit b12, smoking status, dm, htn, cardiovasc dz, bmi Method(s) of assessing cognitive status: DSM NINCDS-ADRDA Informant interview?: Yes, for those who screened positive for dementia | 1) Follow-up rate: 816/937 87%. 2) Important baseline differences: high hcy: older, more women, less APOE e4, less dm, lower vit B, more smokers, more strokes, more cardiovasc dz, 3) Outcome of interest #1 HR for AD 2.08 (1.15 – 3.79) | Comments: 15.3 % of subjects not actually reassessed but information from “subjects themselves, relatives, general practitioners, and death certificates”. No other details were given. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Partial 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Partial 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Rea, Breitner, Psaty, et al., 2005 The Cardiovascular Health Study (CHS) | Geographical location: 4 US communities in NC, SA, MD, & PA Setting: Community Study design: Prospective cohort Number of participants enrolled: 2798 Duration of follow up: Mean = 6 yrs Time from risk factor assessment to final cognitive assessment: Median 5 yrs? | Age: NR Mean 71–72 for 5888 participants in the parent study Sex: Female: NR Male: NR (Reported in person years) Race/ethnicity: NR Baseline cognitive status: Non-demented Inclusion criteria: Living in study community; ≥65 yo; able to respond to questions Exclusion criteria: Dementia; institutionalized; CA Tx; wheelchair-bound | Risk factor/exposure 1: Statin Method of assessing risk factor/exposure 1: Direct measurement – baseline use from Rx bottles; reassessed annually Risk factor/exposure 2: Age, sex, education level, baseline alcohol consumption, coronary heart disease, stroke status Method of assessing risk factor/exposure 2: Self-report Covariates/potential confounders adjusted for in analyses: age, sex, educational level, baseline alcohol consumptin, baseline MMSE, coronary heart disease status, stroke status. Method(s) of assessing cognitive status: NINCDS-ADRDA OR DSM-IV Other – Included CESD for depression Informant interview?: Yes | 1) Follow-up rate: > 95% HR for AD (95% CI) Adjusted for age, sex, educational level, baseline alcohol consumptin, baseline MMSE, coronary heart disease status, stroke status. Never use (216 events/1,000 person years), HR 1 (ref) Stain ever use (21 events/1,000 person years) HR 1.21 (0.76 to 1.91) HR for mixed AD/Vascular Dementia (95% CI) Adjusted for age, sex, educational level, baseline alcohol consumptin, baseline MMSE, coronary heart disease status, stroke status. Never use (137 events/1,000 person years), HR 1 (ref) Stain ever use (9 events/1,000 person years) HR 0.87 (0.44 to 1.72) No dose-response for duration of statin use. HR (95% CI) for AD < 1 year statin: 1.52 (0.78 to 2.98) 1 to 3 years statin: 1.05 (0.49 to 2.24) > 3 years statin: 1.04 (0.42 to 2.56) No relationship with statin lipophilia Lipophilic HR 1.03 (0.57 to 1.86) Less lipophiilic: HR 1.58 (0.80 to 3.11) Sensitivity analysis show no difference when restricted to subjects with clinical CAD or Total cholesterol >/200 mg/dl; No interactin effects between statins and - age >75 vs. younger; sex; race; smoling status, HTN, DM, clinical cerebrovascular disease, APOEe4 genotype, CRP. | Comments: Overlapping sample with Bernick, et al., 2005, but with different outcomes reported Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Yes 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Partial 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Reitz, den Heijer, van Duijn, et al., 2007 Rotterdam Study | Geographical location: Ommoord District of Rotterdam, The Netherlands Setting: Community Study design: Prospective cohort Number of participants enrolled: 6868 Duration of follow up: Mean follow-up 7.3 ± 4.3 yrs Time from risk factor assessment to final cognitive assessment: mean follow-up 7.1 yrs | Age: Mean (SD): 69.5 (9.1) Sex: [n (%)] Female: 4221 (59.9%) Male: 2647 (40.1%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Participation in the Rotterdam Study Exclusion criteria: Prevalent dementia; missing information on smoking history | Risk factor/exposure 1: smoking Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Sex Educational level ETOH use apoE Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Informant interview?: Yes (at least for those who refused cognitive eval) or who had CAMDEX as second stage of case identification. | 1) Follow-up rate: reports follow-up rate of 99.9% with respect to dementia 2) Important baseline differences: NR 3) Outcome of interest #1 Current smokers had greater risk of incident AD 4) Outcome of interest #2 Current smokers without an APOE e4 allele had greater risk of incident AD 5) Outcome of interest #3 Current smokers with an APOE e4 allele were not at greater risk of incident AD | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: yes 2) Selection minimizes baseline differences in prognostic factors?: yes 3) Sample size calculated/5% difference?: Can’t tell 4) Adequate description of the cohort?: yes 5) Validated method for ascertaining exposure?: yes 6) Validated method for ascertaining clinical outcomes?: yes 7) Outcome assessment blind to exposure?: no 8) Adequate follow-up period?: yes 9) Completeness of follow-up?: yes 10) Analysis controls for confounding?: yes 11) Analytic methods appropriate?: yes
Reitz, Luchsinger, Tang, et al., 2005 WHICAP | Geographical location: Washington Heights, Hamilton Heights, and Inwood, in northern Manhattan, NY Setting: Community Study design: Prospective cohort Number of participants enrolled: 791 Duration of follow up: About 5 years Time from risk factor assessment to final cognitive assessment: about 5 years | Age: Mean (SD): 75.6 (5.4) Sex: [n (%)] Female: 558 (70.5%0 Male: 233 (29.5%) Race/ethnicity: [n (%)] Hispanic 384 (48.6%) White 152 (19.2%) Black 250 (31.6%) DK 5 (0.6%) Baseline cognitive status: Normal Inclusion criteria: Medicare recipients ≥ 65 yo; without dementia or cognitive impairment; provided complete smoking information; had at least 3 f/u visits Exclusion criteria: Dementia or CIND @ baseline; smoking information unavailable; < 3 f/u visits | Risk factor/exposure 1: smoking Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level HTN, Heart disease DM APOE Method(s) of assessing cognitive status: Other – decline on cognitive tests Informant interview?: No | 1) Follow-up rate: only included subjects who have 3 waves of follow-up 791/1613 (not demented at baseline and had smoking data available) 2) Important baseline differences: Current smokers more likely to be male and more likely to be African American 3) Outcome of interest #1 Current or past smoking was not associated with more rapid cognitive decline in the whole sample (p = 0.2) 4) Outcome of interest #2 Current smokers > 75 years showed greater decline on memory tasks (p=0.02). There was no significant difference by smoking status for those ≤ 75 years or on any subgroup on the abstract/visuospatial tasks. 5) Outcome of interest #3 In those without an APOE e4 allele, the current smoking was associated with increased risk of decline on memory among those > 75 yrs. There was no significant difference for those ≤ 75 years, the abstract/visuospatial tasks or individuals with at least one APOE e4 allele. | Comments: Question 2 Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: can’t tell 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Partially 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Reitz, Tang, Manly, et al., 2007 Washington Heights – Inwood Columbia Aging Project (WHICAP) | Geographical location: Northern Manhattan, NY, USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 1772 Duration of follow up: baseline (1992–94) then every 18 mos. for three additional waves; mean of 4.7 years Time from risk factor assessment to final cognitive assessment: Mean of 4.7 years | Age: Mean (SD): 76.3 (6.1) Sex: Female: 69.4% Male: 30.6% Race/ethnicity: White 22.6% Black 33.6% Hispanic 43.9% “(percentages do not total 100 because of rounding)” Baseline cognitive status: Non-demented Not mci Inclusion criteria: No MCI or dementia at baseline Had at least one follow-up interval Had complete information to ascertain MCI Exclusion criteria: Prevalent dementia Prevalent MCI Unavailable for follow-up | Risk factor/exposure 1: HTN at baseline Method of assessing risk factor/exposure 1: Self-report Direct measurement Covariates/potential confounders adjusted for in analyses: Age, Race, Sex Educational level, apoE4, stroke, dm, heart disease, LDL level Method(s) of assessing cognitive status: Petersen’s criteria referenced but not really Informant interview?: Petersen’s criteria referenced but informant missing | 1) Follow-up rate: “about half” were evaluated at the third follow up for one section (change over time) it says 79% had at least 3 intervals, 59% had 4 or more intervals, but it doesn’t say if this is really the whole sample 2) Important baseline differences: NR 3) Outcome of interest #1 risk of all cause mci with htn 1.2 (0.81 – 1.69) amnestic mci 0.90 (0.54 – 1.47) nonamnestic mci 1.60 (0.93 – 2.85) | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Partial 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Partial 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Can’t Tell 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Reitz, Tang, Luchsinger, et al., 2004 Washington Heights – Inwood – Columbia Aging Project (WHICAP) | Geographical location: Northern Manhattan, NY, USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 4316 Duration of follow up: 4.8 +/− 2.9 years Time from risk factor assessment to final cognitive assessment: 4.8 +/− 2.9 years | Age: Range: ≥ 65 years Sex: [n (%)] NR Race/ethnicity: NR Baseline cognitive status: Non-demented Inclusion criteria: Medicare recipients ≥ 65 years of age Residing in northern Manhattan, NY Exclusion criteria: Prevalent dementia Race other than those listed above No blood available | Risk factor/exposure 1: Plasma lipids Method of assessing risk factor/exposure 1:direct measurement cholesterol and lipid profile measured by fasting blood sample obtained at initial assessment Risk factor/exposure 2: Diabetes mellitus Method of assessing risk factor/exposure 2: self-report Risk factor/exposure 3: hypertension Method of assessing risk factor/exposure 3: self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Additional models adjusted for: BMI, diabetes mellitus, hypertension, heart disease and APOE4 genotype Method(s) of assessing cognitive status: [delete all that do not apply] NINCDS-ADRDA Informant interview?: NR | 1) Follow-up rate: 1168/2126 = 54.9% 2) Important baseline differences: NR 3) Outcome of interest #1 Total cholesterol: lower cholesterol is associated with lower risk of AD in a model adjusted for BMI, APOE, diabetes, heart disease and hypertension (trend test P=.04), but does not reach significance in a model adjusted for sex, age, education and race (trend test P=.07). No other factors reached significance in either model (Non-HDL-C, HDL-C, triglycerides or LDL-C) 4) Outcome of interest #2 Diabetes-no statistics calculated. 119 cases incident AD 5 untreated diabetics (4.2%); 18 treated diabetics (15.1%) 635 control subjects. 29 untreated diabetics (3.9%) 86 treated diabetics (11.5%) 5) Outcome of interest #3 Hypertension-no statistics calculated. 119 cases incident AD 22 untreated htn (18.5%) 39 treated htn (32.8%) 635 control subjects 125 (16.8%) untreated htn 275 (36.9%) treated htn | Comments: Analysis for diabetes and hypertension limited. Only percentage of people with DM and HTN in incident AD and control groups reported. Self report of diabetes and hypertension at baseline. Not clear if also asked at follow-up. Both hypertension and diabetes are likely to be under-identified by self-report. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Assessment of risk factor? Yes 6) Assessment cognitive outcome: Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Rondeau, Jacqmin-Gadda, Commenges, et al., 2009 PAQUID | Geographical location: Gironde and Dordogne, France Setting: Community Study design: Prospective cohort Number of participants enrolled: 1925 Duration of follow up: 11.3 yrs (mean) Time from risk factor assessment to final cognitive assessment: Uncertain, but estimated range from 0–8 yrs (Not entirely clear that all exposure data collected prior to time point for final cognitive outcome) | Age: At 10 yr f/u: Mean (SD): PAQUID sample: 82.5 ALMA sample: 82.3 Sex: [n (%)] Female: 1,181 (61.4) Male: 744 (38.6) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Age ≥65, living at home, in specific region of France Exclusion criteria: None except as covered by inclusion criteria | Risk factor/exposure 1: exposure to aluminum in drinking water Method of assessing risk factor/exposure 1: Self-report Other – chemical analyses of drinking water in geographic area Covariates/potential confounders adjusted for in analyses: Age Gender Educational level Wine consumption Place of residence (urban vs rural) Cohort (ALMA or PAQUID) Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Other – change over time on MMSE Informant interview?: No | 1) Follow-up rate: 1925/3970 nondemented at baseline 2) Important baseline differences: Statistical comparisons NR 3) Outcome of interest #1 Greater decline on MMSE for every 0.1 mg/day higher aluminum intake based on daily consumption (p=0.001) or geographic exposure (<0.001). Silica intake was not associated with cognitive decline. Associations no longer significant when the demented were excluded suggesting that aluminum intake only associated with decline as part of the dementing process. 4) Outcome of interest #2 RR = 1.34 (95% CI: 1.09–1.65) – increased risk of AD for ≥0.1mg/day consumption of aluminum. No dose-response relationship 5) Outcome of interest #3 R=0.88 (95% CI: 0.79–0.99) lower risk of AD for each 10 mg/day higher intake of silica Exposure to aluminum or silica based on geographic exposure not associated with AD | Comments: Questions 1, 2, – no cat Dx Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Partial 5) Validated method for ascertaining exposure? Partial 6) Validated method for ascertaining clinical outcomes? Partial 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Partial 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Rovio, Kareholt, Helkala, et al., 2005 Cardiovascular risk factors, Aging and Incidence of Dementia (CAIDE) study North Karelia Project FINMONIC A study | Geographical location: Kuopio & Joensuu, Finland Setting: Community Study design: Prospective cohort Sampled once at midlife (1972, 1977, 1982 or 1987) and again in 1998 Number of participants enrolled: 1449 of 2000 randomly selected (72.5%) Duration of follow up: 21 yrs (SD 4.9) Time from risk factor assessment to final cognitive assessment: 21 yrs (SD 4.9) | Age: [underlined: At midlife exam:] Mean (SD): 50.6 (6.0) Range: 39–64 [underlined: At re-examination:] Mean (SD): 71.6 (4.1) Range: 65–79 Sex: Female: 900 (62.1%) Male: 549 (37.9%) Race/ethnicity: NR Baseline cognitive status: NR but unlikely had cognitive impairment in midlife at baseline Inclusion criteria: Survivors of 4 separate samples of the North Karelia Project and FINMONICA study, lived in 2 geographically defined areas; complete data on outcome, physical activity, and covariates. Exclusion criteria: NR | Risk factor/exposure 1: Leisure-time physical activity at midlife Method of assessing risk factor/exposure 1: Self-report: “How often do you participate in leisure-time physical activity that lasts at least 20–30 minutes and causes breathlessness and sweating?” “active” = active ≥ 2 times/wk “sedentary” = < 2 times/wk Covariates/potential confounders adjusted for in analyses: Age Sex Educational level f/u time locomotor disorders APOE Clinical variables Smoking status Alcohol use Method(s) of assessing cognitive status: MMSE for screening (<24 MMSE score) NINCDS-ADRDA DSM-IV Informant interview?: No | 1) Follow-up rate: 1449 of 2000 randomly selected (72.5%) participated. 434 refused f/u, and 107 refused due to poor health (total refusals = 551). F/U rate not calculable 2) Important baseline differences: Those who were sedentary were slightly younger at baseline and slightly longer f/u interval. Relatively more women than men were sedentary. 3) Outcome of interest #1 61 incident cases of dementia (48 had AD) 4) Outcome of interest #2 Dementia (n=1251) Crude OR 0.55 (95% CI, 0.30–1.01) Fully adjusted OR 0.47 (0.25–0.90) 5) Outcome of interest #3 AD (n=1239) Physical activity reduced the risk of AD in all 4 models (crude and 3 adjusted). Active individuals had approximately 60% lower odds of AD than sedentary ones. Crude OR 0.45 (95% CI, 0.22–0.93) Fully adjusted OR 0.35 (0.16–0.80) Physical activity had same effect on both sexes. APOE appears to be an effect modifier: among APOE carriers there is an association between physical activity and AD, but not among non-carriers. | Comments: Rovio 2007 updates this analysis Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? No (exercise assessment) 6) Validated method for ascertaining clinical outcomes? Partial. Only those with MMSE<24 had full evaluation. 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Rovio, Kareholt, Viitanen, et al., 2007 Cardiovascular risk factors, Aging and Incidence of Dementia (CAIDE) study North Karelia Project FINMONIC A study | Geographical location: Kuopio & Joensuu, Finland Setting: Community Study design: Prospective cohort Sampled once at midlife (1972, 1977, 1982 or 1987) and again in 1998 Number of participants enrolled: 1449 Duration of follow up: Mean: 20.9 years (SD 4.9) Time from risk factor assessment to final cognitive assessment: 21 years (mean) | Age: [underlined: At midlife exam:] Mean (SD): 50.4 (6.0) Median: Range: 39–64 [underlined: At re-examination:] Mean (SD): 71.3 (4.0) Median: Range: 65–79 Sex: Female: 900 (62.1%) Male: 549 (37.9%) Race/ethnicity: NR Baseline cognitive status: NR, but unlikely they were impaired at baseline in midlife Inclusion criteria: Survivors of 4 separate samples of the North Karelia Project and FINMONICA study; lived in two geographically defined areas; complete data on outcome, physical activity, and covariates Exclusion criteria: NR | Risk factor/exposure 1: Work-related physical activity Method of assessing risk factor/exposure 1: Self-report [underlined: Occupational physical activity:] “How physically heavy is your work?” Dichotomized to sedentary vs. active groups. Dichotomization point NR. [underlined: Total daily commuting physical activity:] “How many minutes do you walk, bicycle, or have some other physical activity when you are going to and from work?” Categorized: 1) not at all 2) ≤ 59 minutes 3) ≥ 60 minutes Covariates/potential confounders adjusted for in analyses: Age Sex Educational level F/u time Locomotor symptoms Occupation Income at midlife Leisure physical activity APOE Vascular disorder Smoking status Method(s) of assessing cognitive status: MMSE for screening (screen + if score ≤24) NINCDS-ADRDA DSM-IV Informant interview?: No | 1) Follow-up rate: 1449 of 2000 randomly selected (72.5%). Remaining 27.5% “non-participants.” Missing data on independent variables in 291 persons. Analytical sample = 1158 (57.9%) 2) Important baseline differences: NA 3) Outcome of interest #1 44 incident cases of dementia (33 AD). 4) Outcome of interest #2 Neither occupational (OR, 1.90; 95% CI, 0.73–4.95) nor commuting physical activity (OR, 0.48; 95% CI 0.09–2.58) were associated with the risk of AD. | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? No 6) Validated method for ascertaining clinical outcomes? Partial 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? No 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Ryan, Carriere, Scali, et al., 2009 ESPRIT substudy | Geographical location: Montpelier, France Setting: Community Study design: Prospective cohort Number of participants enrolled: 996 Duration of follow up: 4 yrs Time from risk factor assessment to final cognitive assessment: Lifetime | Age: Mean (SD): 72.8 (5.5) Sex: [n (%)] Female: 996 (100%) Male: 0 (0%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: ≥65 yrs, non-institutionalized and resided in Montpelier, France Exclusion criteria: None except as covered by exclusion criteria | Risk factor/exposure 1: lifetime estrogen exposure Method of assessing risk factor/exposure 1: Self-report of reproductive factors associated with estrogen exposure and use of exogenous hormone treatment Covariates/potential confounders adjusted for in analyses: Age Educational level Marital status Depressive symptoms Caffeine intake Physical impairment Medical conditions Baseline cognitive status Method(s) of assessing cognitive status: DSM Other – substantial decline on cognitive tests defined as lowest quintile of the difference between baseline score and score at either of the follow-up visits Informant interview?: No | 1) Follow-up rate: 996/1277 of non-demented at baseline 2) Important baseline differences: NR 3) Outcome of interest #1 In fully adjusted model, no association between lifetime estrogen exposure and risk of substantial decline on any cognitive measures | Comments: Question 2 – cat Dx Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Partial 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Saczynski, Pfeifer, Masaki, et al., 2006 HAAS Honolulu Asia Aging Study | Geographical location: Honolulu, Hawaii Setting: Community Study design: Prospective cohort Number of participants enrolled: 3,508 Duration of follow up: 27.5 (mean) yrs for midlife social measures and 4.6 (mean) yrs for late life Time from risk factor assessment to final cognitive assessment: 27.5(mean) yrs for midlife social measures and 4.6 (mean) yrs for late life | Age: Mean (SD): 76.8 years Sex: [n (%)] Female: 0 (0%) Male: 2513 (100%) Race/ethnicity: [n (%)] All of Japanese origin. Baseline cognitive status: Non-demented Inclusion criteria: Japanese-American men born between 1900 and 1919 who were living on the island of Oahu, Hawaii, at the time of enrollment in 1965 Exclusion criteria: Those who had dementia at the 1991 exam were excluded from the incident cohort. | Risk factor/exposure 1: Social engagement Method of assessing risk factor/exposure 1: Self-report marital status; living arrangement; participation in social, political, or community groups; participation in social events with coworkers; and the existence of a confidant relationship (composite score of the above) Covariates/potential confounders adjusted for in analyses: Age Education Cognitive Abilities Screening Instrument score, apolipoprotein E e4 allele status, History of stroke, coronary heart disease, depression, and disability Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Informant interview?: Yes | 1) Follow-up rate: Of 3,508, 521died before examination 5, 359 did not participate in examination 5, and 115 had missing data Final sample: 2,513 men Excluding those who died, rate of follow up was 84.13% 2) Important baseline differences: Compared with men who died or dropped out of the sample, those who survived were younger and had higher CASI scores, more education, less cerebrovascular disease, less coronary heart disease, and less impairment in activities of daily living Those with low mid-life or late-life social engagement scores were older at baseline. 3) Outcome of interest #1 222 men diagnosed with incident dementia, 134 (60%) had Alzheimer’s disease, 47 had vascular dementia, and 41 had other types of dementia 4) Outcome of interest #2 Midlife social engagement not associated with incident dementia. Compared to those who had highest social engagement in late life, those who had the lowest social engagement had a higher risk of developing dementia. HR= 2.34 (1.18, 4.65) 5) Outcome of interest #3 Compared to those who had consistently high social engagement in mid and late life, those whose social engagement decreased from mid to late life had a higher risk of incident dementia. HR= 1.87 (1.12, 3.13) | Comments: Question 1 Results presented for all cause dementia. No individual results for AD though the text mentions that they analyzed AD separately and found similar results. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Partial 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Saxby, Harrington, Wesnes, et al., 2008 Study on Cognition and Prognosis in the Elderly (SCOPE) | Geographical location: Tyneside, UK (one site from a multi-center trial) Setting: Clinical Study design: RCT Test intervention: Candesartan 8–16mg; mean dose = 12 mg Other antihypertensives allowed Comparator intervention(s): Placebo, other antihypertensives allowed Number of participants enrolled: 257; 228 available for analysis Duration of follow up: mean 44 mos, (12), range 12 – 60 mos Time from risk factor assessment to final cognitive assessment: rct administered meds | Age: Mean: 76 years Range: 70 –89 years Sex: [n (%)] (of those available for analysis) Female: 107 (47%) Male: 121 (53%) Race/ethnicity: [n (%)] NR Baseline cognitive status: eliminated theoretically those who had mmse < 24 or who had sig decline in cdr and iqcode but no one was actually eliminated using these criteria Inclusion criteria: Hypertensive 70 – 89 years Exclusion criteria: MMSE score < 24 Reported significant decline in cognitive function | Covariates/potential confounders adjusted for in analyses: age, number of errors on the New Adult Reading Test, baseline cognitive performance Method(s) of assessing cognitive status: change in test score measured every 12 months in 5 domains: Episdoic memory (5 tests); Attention (3 tests); Working memory (2 tests); Speed of cognition (# tests not given); Executive function (4 tests) Informant interview? no | 1) Follow-up rate: 159/228 completed maximum number of assessments − 70%; 228/257 analyzed = 88.7%, average proportion of the follow up period spent on active tx was 88% 2) Important baseline differences: “no baseline difference between the candesartan and placebo groups” 3) Outcome of interest #1 change in cognition between the candesartan and placebo groups as measured by coef of decline on five composite factor factor scores significant for attn (candesartan = 0.004 vs. placebo −0.036, effect size = 0.28, p= 0.04) and episodic memory (0.14 vs. −0.22, effect size = 0.28, p=0.04) but not for speed of cognition, working memory or executive functioning. | Comments: subj 70–89 yrs old, sbp 160 – 179 mmHg, dbp 90–99 mmHg or both For scope overall, hctz was added to 49% of candesartan group and 66% of the control group. One site from a multi-center trial (see Skoog, Lithell, Hansson, et al., 2005); only 257 out of 4937 participants included in analysis. Quality assessment: For RCTs: 1) Baseline comparability? Yes 2) Valid AD/cognitive outcomes assessment? Yes 3) Subjects/providers blind? Can’t Tell (double-blind but specific blind not specified) 4) Outcome assessors blind? Yes 5) Incomplete data adequately addressed? Yes 6) Differential dropout rate < 10%? Yes 7) Overall dropout rate < 30%? Yes 8) Conflict of interest reported and insignificant? No. AstraZenac sponsored, but not involved in analysis. 9) Randomization adequate? Yes 10) Allocation concealment adequate? Can’t Tell
Scarmeas, Levy, Tang, et al., 2001 | Geographical location: Manhattan, NY Setting: Community Study design: Prospective cohort Number of participants enrolled: 1772, from 2126 of 3452 initially eligible persons. Duration of follow up: Mean 2.9 yrs (range: 0–7.2) Time from risk factor assessment to final cognitive assessment: Mean 2.9 yrs (range: 0–7.2) | Age: [underlined: Incident dementia:] 78.2 ± 6.5 [underlined: No incident dementia:] 75.3 ±6.2 Sex: Females: [underlined: Incident dementia:] 69% [underlined: No incident dementia:] 68% Males: [underlined: Incident dementia:] 31% [underlined: No incident dementia:] 32% Race/ethnicity: NR Baseline cognitive status: Non-demented Inclusion criteria: Cohort identified from a probability sample of Medicare beneficiaries residing in northern Manhattan. 65 years or older, non- demented, seen for at least one follow-up evaluation. Exclusion criteria: Recent h/o stroke or Parkinson’s Disease | Risk factor/exposure 1: Leisure activities Method of assessing risk factor/exposure 1: Self-report. Asked about 13 different activities. When dichotomized, “low”= ≤6 and “high” = >6 Covariates/potential confounders adjusted for in analyses: Ethnicity Sex Educational level Occupation Clinical variables Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Other – Care Diagnostic Interview, clinical evaluation, neuropsych eval. Informant interview?: No | 1) Follow-up rate: 2126 initially selected. 327 demented at 1^st^ eval and excluded, leaving 1799. Leisure activity available for final sample of 1772. 1772/2126 = 83% 2) Important baseline differences: NA 3) Outcome of interest #1 207 incident cases of dementia (153 with probable or possible AD) 4) Outcome of interest #2-- dementia With activity as a continuous variable in an age-stratified Cox model, higher scores were associated with a reduced risk of dementia (RR, 0.88; 95% CI, 0.83–0.93). Associate remained after adjusting for ethnicity, education, and occupation. There appears to be a synergistic effect of leisure activities and education, and leisure activities and occupation. 5) Outcome of interest #3--D No results about AD other than reporting that 153 participants had probable or possible AD at f/u, and that 27 had possible AD with concomitant stroke. | Comments: All of the results are for dementia, but the authors make conclusions about AD. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Partial 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? No 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Scarmeas, Luchsinger, Schupf, et al., 2009 WHICAP | Geographical location: New York, New York Setting: Community Study design: Prospective cohort Number of participants enrolled: 1880 Duration of follow up: Mean (sd): 5.4 (3.3) yrs Time from risk factor assessment to final cognitive assessment: NR | Age: Mean (SD): 77.2(6.6) Sex: [n (%)] Female: 1293 (69) Male: 587 (31) Race/ethnicity: [n (%)] White 531 (28) Black 605 (32) Hispanic 715 (38) Other 29 (2) Baseline cognitive status: Non-demented Inclusion criteria: Cohort identified from a probability sample of Medicare beneficiaries residing in northern Manhattan. 65 years or older, non-demented, seen for at least one follow-up evaluation. Exclusion criteria: NR | Risk factor/exposure 1: Physical activity and nutrition Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level BMI Smoking Depression Leisure activities Comorbid medical conditions Baseline CDR score APOE Interval between 1^st^ dietary and 1^st^ physical activity measure Caloric intake Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Informant interview?: No | 1) Follow-up rate: 1880/2247 with dietary and physical activity data 2) Important baseline differences: Less physically active individuals were more likely to be female, older, Hispanic, smokers, depressed, less educated, had a lower total caloric intake, higher BMI, more comorbid illnesses, and adhered less to the diet. 3) Outcome of interest #1 Considered simultaneously, both adherence to a Mediterranean-type diet (compared with low diet score) HR for middle diet score was 0.98 [95% CI, 0.72–1.33]; the HR for high diet score was 0.60 [95% CI, 0.42–0.87]; P=.008 for trend) and physical activity compared with no physical activity, the HR for some physical activity was 0.75 [95% CI, 0.54–1.04]; the HR for much physical activity was 0.67 [95% CI, 0.47–0.95]; P=.03 for trend) were associated with lower AD risk. 4) Outcome of interest #2 Compared with individuals neither adhering to the diet nor participating in physical activity (low diet score and no physical activity; absolute AD risk of 19%), those both adhering to the diet and participating in physical activity (high diet score and high physical activity) had a lower risk of AD (absolute risk, 12%; HR, 0.65 [95% CI, 0.44–0.96]; P=.03 for trend). | Comments: Question 1 Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Yes 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Partial 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Scarmeas, Stern, Mayeux, et al., 2009 WHICAP subsets | Geographical location: Northern Manhattan, NY Setting: Community Study design Prospective cohort Number of participants enrolled: 1875 1393 cog normal 482 MCI Duration of follow up: 4.5 (2.7) years range 0.9–16.4 yrs Time from risk factor assessment to final cognitive assessment: evaluated every 1.5 yrs time between cog assessment and dietary assessment | Age: Mean (SD): 76.9 (6.5) Cog norm 76.7 (6.5) MCI 77.5 (6.6) Sex: [n (%)] Female: 1272 (68%) Cog norm 946 (68%) MCI 326 (68%) Male: 603 (32%) Cog norm 447 (32%) MCI 156 (32%) Race/ethnicity: [n (%)] White 558 (30%) Cog norm 434 (31%) MCI 124 (26%) Black 623 (33%) Cog norm 479 (34%) MCI 144 (30%) Hispanic 687 (36%) Cog norm 473 (34%) MCI 214 (44%) Other 7 (1%) Cog norm 7 (1%) MCI 0 (0%) Baseline cognitive status: Non-demented Inclusion criteria: Participated in either 1992 or 1999 WHICAP study, Medicare beneficiary, residing in a designated geographic area of northern Manhattan, NY Exclusion criteria: NR | Risk factor/exposure 1: Mediterranean diet Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age, Race, Sex, education, apoE, bmi, time betw dietary assessment and cog assessment, Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Mci dx’d retrospectively Informant interview?: No | 1) Follow-up rate: subject pool selected from larger study cohort on basis on cognitive status and follow up. 2) Important baseline differences: Hispanic subjects adhered more to med. Diet. Black subj adhered less, higher adherence associated with lower caloric intake. 3) Outcome of interest #1 using lowest tertile of adherence as reference, middle tertile had hr 0.83 (0.62 – 1.12), highest tertile hr 0.72 (0.52–1.00) for development of mci 4) Outcome of interest #2 for progression from mci to ad, middle tertile hr 0.55 (0.34 – 0.90), highest tertile hr 0.52 (0.30 – 0.91) | Comments: Questions 1 & 2 – yes cat Dx Diagnosis of mci applied retrospectively. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Partial 6) Validated method for ascertaining clinical outcomes? No 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Can’t Tell 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Scarmeas, Stern, Tang, et al., 2006 WHICAP | Geographical location: Northern Manhattan, NY, USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 2,258 Duration of follow up: Mean= 4.0 (3.0) yrs Range = 0.2–13.9 yrs Time from risk factor assessment to final cognitive assessment: Estimated − 2.5 yrs – risk factor data collected at 1^st^ follow-up and follow-ups were every 1.5 yrs | Age: Mean (SD): 77.2 (6.6) Sex: [n (%)] Female: 1514 (68) Male: 720 (32) N slightly different than total N due to non-AD dementia Race/ethnicity: [n (%)] AA 722 (32) White 620 (28) Hispanic 848 (38) Other 36 (2) N slightly different than total N due to non-AD dementia Baseline cognitive status: Non-demented Inclusion criteria: Medicare recipients age ≥65 residing in Northern Manhattan. Two separate cohorts were used WHICAP 1992 and WHICAP 1999. Exclusion criteria: None | Risk factor/exposure 1: Mediterranean diet Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Sample cohort APOE Caloric intake Smoking Medical comorbidity index BMI Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Informant interview?: No | 1) Follow-up rate: 2258/2784 (denominator excludes those who did not participate in fup due to death) 2) Important baseline differences: Ind who developed dementia were older, less educated, and had higher BMI. Among those who developed dementia, there was a higher proportion of Hispanics and a lower proportion of whites. 3) Outcome of interest #1 Higher adherence to a Mediterranean diet was associated with decrease in risk of AD: Continuous measure of Mediteranean diet (HR=0.91; 0.83–0.98) Categorical measure: High tertile (HR=0.60; 0.42–0.87) | Comments: Question 1 Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Partial 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Schaefer, Bongard, Beiser, et al., 2006 Framingham | Geographical location: Framingham, MA, USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 899 Duration of follow up: 9.1 yrs Time from risk factor assessment to final cognitive assessment: 9.1 yrs | Age: Mean (SD): 76 (5.0) yrs Sex: [n (%)] Female: 571 (63.5) Male: 328 (36.5) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: In 1948, men and women between the ages of 30 and 62 from the town of Framingham, MA followed with biennial exams since Exclusion criteria: none | Risk factor/exposure 1: DHA Method of assessing risk factor/exposure 1: Direct measurement Self-report Method of assessing risk factor/exposure 2: Self-report Proxy report Direct measurement Medical record Other Covariates/potential confounders adjusted for in analyses: Age Sex Educational level APOE Homocysteine Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Informant interview?: Yes | 1) Follow-up rate: difficult to get meaningful numbers. 899 had plasma measures out of the 1208 that completed the wave of data collection used as the baseline for these analyses. Then subjects followed until point of censoring. 2) Important baseline differences: NR 3) Outcome of interest #1 Ind in upper quartile of baseline plasma PC DHA levels, compared to lower 3 quartiles, did not have sig lower risk of AD (RR=0.61; 0.31– 1.18). Results for all dementia were significant (RR=0.53; 0.29–0.97) 4) Outcome of interest #2 Ind in upper quartile of dietary intake of DHA, compared to lower 3 quartiles, did not have sig lower risk of AD (RR=0.63; 0.23–1.72) 5) Outcome of interest #3 Ind who consumed fish > twice a week compared to those who consumed fish ≤ twice a week did not have sig lower risk of AD (RR=0.61; 0.28–1.33) | Comments: Question 1 Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Schuit, Feskens, Launer, et al., 2001 Zutphen Elderly Study Seven Countries Study | Geographical location: Zutphen, Netherlands Setting: NR. 88% lived independently at home. Study design: Prospective cohort Number of participants enrolled: 560 – 347 analyzed Duration of follow up: 3 years Time from risk factor assessment to final cognitive assessment: 3 years | Age: Mean (SD): 74.6 ±4.3 Sex: Female: 0 Male: 347 (100%) Race/ethnicity: NR Baseline cognitive status: Did not appear to exclude those with cognitive impairment Inclusion criteria: Participants in the Seven Countries Study aged 65–84 at baseline living in Zutphen. Exclusion criteria: NR | Risk factor/exposure 1: Physical activity Method of assessing risk factor/exposure 1: Self-report. Validated questionnaire for measuring physical activity in elderly men. Summed score for total weekly activity. Categorized: 1) ≤30 min/day 2) 31–60 min/day 3) > 60 min/day Risk factor/exposure 2: APOE phenotype. Method of assessing risk factor/exposure 2: Direct measurement; Isoelectric focusing followed by immunoblotting. Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Smoking Alcohol Baseline cognitive function Clinical variables Disabilities in ADL Health status Method(s) of assessing cognitive status: Cognitive decline defined as a decrease of >3 points on the MMSE. Informant interview?: No | 1) Follow-up rate: 347 of 560 (62%). No information provided on non-responders. Non-response associated with: lower SES, and health status 2) Important baseline differences: NA 3) Outcome of interest #1— Physical activity and CD Age and education adjusted OR (95% CI) for cognitive decline, with > 60 min/day as the reference: < 30 min/day: OR 2.0 (0.7–5.6) 31–60 min/day: OR 1.8 (0.6–5.1) 4) Outcome of interest #2— Interaction of physical activity and APOE with CD – subgroup analysis The OR of cognitive decline among inactive (<=1 hr/day) vs active (>1 hr/day) APOE e4 non-carriers: (OR, 0.9; 95%CI, 0.2–3.2) APOE e4 carriers: (OR, 3.7; 95%CI, 1.1–12.6) | Comments: OR for cognitive decline was 2.0 but not statistically significant in analyses that did not include APOE as an effect modifier. At baseline, 13.5% of subjects had MMSE <=25 Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Can’t tell (inadequate reporting) 2) Selection minimizes baseline differences in prognostic factors?: Can’t tell (inadequate reporting) 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Partially (incomplete description of cohort, but some baseline measure reported in Table 1) 5) Validated method for ascertaining exposure?: Partially (authors claim that the assessment is valid) 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t tell 8) Adequate follow-up period?: can’t tell 9) Completeness of follow-up?: No (f/u rate of 62%) 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Seeman, Lusignolo, Albert, et al., 2001 McArthur Study of Healthy Aging | Geographical location: Durham NC East Boston MA New Haven CT Setting: Community Study design: Prospective cohort Number of participants enrolled: 1189 participated 1145 analyzed Duration of follow up: 7.4 YEARS SD= 4.7 months Time from risk factor assessment to final cognitive assessment: Mean of 7.4 years. | Age: Mean (SD): 74 Sex: [n (%)] Female: 632 (55.2%) Male: 513 (44.8%) Race/ethnicity: [n (%)] AA 206 (18%) White 940 (82%) Baseline cognitive status: Participants who scored in the top third of the cognitive and physical screening tests for their age group. Inclusion criteria: Age between 70–79 Physical: 1)No. reported disability on the 7-item activities of living scale. 2))No more than 1 reported mild disability on eight items tapping gross mobility and range of motion 3)Ability to maintain semi tandem balance for at least 10 s 4) Ability to stand from seated position at least 5 times in 20 s. Cognitive: 1) Scoring at least 6 or more on the SPSMQ 2) Remembering three or more of the six elements on a delayed recall of a short story. Exclusion criteria: NR | Risk factor/exposure 1: Respondents’ perception of their social network using the MacArthur battery which had both qualitative and quantitative components. Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Income Number of reported chronic illnesses Pulmonary function Amount of strenuous leisure activity. Amount of strenuous yard/house maintenance. Depressive symptoms Self efficacy beliefs. Method(s) of assessing cognitive status: Other – Language 18 item Boston Naming test Abstraction: 4 items from the Similarities subtest of the Wechsler’s Adult intelligence scale Spatial ability: Copying image Incidental recall of confrontation naming Delayed recall of a story Informant interview?: Yes Proxy interviews were conducted for some who had missing data. | 1) Follow-up rate: Of 1189, 273 (23%) died before follow up. Of the remaining 916, 722 completed face to face interviews, 107 (11.7% had proxy partial interviews) and the rest refused or could not be contacted. 1145 had complete baseline data and were included in the analyses 2) Important baseline differences: At baseline, among other differences noted, men had higher income and reported more social ties overall but women reported greater involvement in groups. 3) Outcome of interest #1 After controlling for covariates, greater baseline social support was not associated with greater decline on a cognitive summary score at 7.5 year follow up: b= 1.26 p= .07. When the model was reduced by excluding baseline cognitive status and other sociodemographic factors, health status, behavioral and psychological variables, the relationship between baseline emotional support and cognitive decline became significant; b= 1.20, p= 0.05. 4) Outcome of interest #2 Being married (b= − 0.48, p= 0.52); Number of close ties (− 0.02, p=0.75); number of groups(− 0.13, p =0.70) were not significant predictors of cognitive decline over the same time period. | Comments: This population is selective in that the participants were among the top one-third of their age group for functional and cognitive status at baseline. Applicability to general population may be limited. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Partial (but standard for the field at the time) 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Seshadri, Beiser, Selhub, et al., 2002 Framingham | Geographical location: Framingham, MA Setting: Community Study design: Prospective cohort Number of participants enrolled: 1092 Duration of follow up: median 8 yrs (range 1 to 13) Time from risk factor assessment to final cognitive assessment: 8 years on average | Age: Mean (SD): 76 Sex: [n (%)] Female: 667 Male: 425 Race/ethnicity: [n (%)]NR Baseline cognitive status: Non-demented Inclusion criteria: Participation in the Framingham Study Exclusion criteria: Dementia | Risk factor/exposure 1: hcy Method of assessing risk factor/exposure 1: Direct measurement Plasma, frozen, fasting status not indicated so most likely not. Covariates/potential confounders adjusted for in analyses: age, sex, apoE, folate and vitamins b12 and b6, education, stroke, smoking, alcohol, dm, bmi sbp at baseline Method(s) of assessing cognitive status: NINCDS-ADRDA DSM In subjects with abnormal MMSE screen Informant interview?: Yes | 1) Follow-up rate: 77% of those alive who had been free of dementia participated in this baseline visit 2) Important baseline differences: NR 3) Outcome of interest #1 Dementia n=111 (83 AD) For each 1 SD increase in log-transformed homocysteine, RR of AD fully adjusted for total hcy 1.8(1.3 – 2.5) For homocysteine>14 umol/l , adjusted HR = 1.9 (95% CI 1.2–3.0) 4) Outcome of interest #2 No association between folate, B12, B6 and incident AD (data not given) | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Partial, would like baseline comparison based on hcy 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes but in fully adjusted model, there were only 54 AD cases and a lot of covariates 11) Analytic methods appropriate? Partial, may have overfit models given number of cases
Shadlen, Larson, Wang, et al., 2005 ACT | Geographical location: Seattle, WA Setting: Other - HMO Study design: Prospective cohort Number of participants enrolled: 2581 enrolled from ACT 2410 declared race 2168 had APOE data 2140 were analyzed @ f/u Duration of follow up: 3.29 years (1.36) Time from risk factor assessment to final cognitive assessment: 3.29 years (1.36) | Age: (from 2410 @ baseline) Mean (SD): 75.4 (6.2) Range: 65 - >85 Sex: [n (%)] (from 2410 @ baseline) Female: 1431 (59.4%) Male: 979 (40.6%) Race/ethnicity: [n (%)](from 2410 @ baseline) White 2307 (95.7%) Black 103 (4.3%) Baseline cognitive status: Non-demented Inclusion criteria: Enrolled in ACT study; free of dementia; not institutionalized; age ≥65, member of Group Health Cooperative (HMO) Exclusion criteria: Dementia, living in nursing home | Risk factor/exposure 1: APOE Method of assessing risk factor/exposure 1: Direct measurement Risk factor/exposure 2: education Method of assessing risk factor/exposure 2: Self-report Risk factor/exposure 3: Depression Method of assessing risk factor/exposure: CES-D Risk facot/exposure 4: Diabetes mellitus Method of assessing risk factor/exposure: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Years of followup Depression Diabetes Hypertension Cerebrovascular disease Method(s) of assessing cognitive status: ] NINCDS-ADRDA DSM Other – longitudinal change in CASI score Informant interview?: No | 1) Follow-up rate: 2140 with APOE and f/u data. Difficult to extract exact f/u rate. 165 discontinued and 366 died during study = 75.2% f/u rate 2) Important baseline differences: NR 3) Outcome of interest #1 Education as a continuous measure was not associated with cognitive decline. 4) Outcome of interest #2 Compared to individuals without an APOE4 allele, individuals with a single APOE4 allele did not have greater CASI decline. But individuals with two APOE4 alleles experienced greater decline in cognitive performance and the magnitude of that decline decreased as years of educational attainment increased. (coefficient =0.51 (95% CI 0.12, 0.91; P = 0.011)). Generalized estimating equation analysis (GEE) Risk factors associated with change in global cognitive performance No E4 reference One E4 allele coef=−0.23 (−2.5, 2.05) P=0.846 Two E4 alleles coef=−10.08 (−16.24, − 3.92) P=0.001 Interaction of APOE4 and education One E4 x education coef .002 (−.15, .16) P=.976 Two E4 x education coef 0.51 (.12, .91) P=.011 Outcome of interest #3 Generalized estimating equation Diabetes mellitus No-reference Yes- coef −.59 (−1.14, −.04) P=.001 | Comments: Q2 – no cat Dx Depressive symptoms assessed at last f/u; therefore these results cross- sectional and not used. At 4-yr f/u, 138 (6%) of the original sample had declines in their CASI scores by 1.5 standard deviations (7 points) or greater. Subjects who were diagnosed with dementia during the study were not included in analysis. Author’s Conclusions: Lower education was associated with steep 4-yr cognitive decline for APOE4 homozygotes but not for APOE4 heterozygotes. Potentially modifiable host factors such as education could influence the association of high-risk genotypes and cognitive decline. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Shah, Wilson, Bienias, et al., 2006 Religious orders study | Geographical location: 40 groups across US Setting: Community Study design: Prospective cohort Number of participants enrolled: 990 in study overall; 824 in this analysis Duration of follow up: mean of 6.5 annual clinical evaluations Time from risk factor assessment to final cognitive assessment: NR, annual assessments | Age: Mean (SD): 75 (7) Sex: [n (%)] Female: 569 (69%) Male: 255 (31%) Race/ethnicity: [n (%)] White 750 (91%) Other 74 (9%) Baseline cognitive status: Non-demented Inclusion criteria: Participation in Religious Orders Study; agreement to annual clinical evaluations; no dementia @ baseline Exclusion criteria: No f/u evaluation | Risk factor/exposure 1: htn Method of assessing risk factor/exposure 1: Direct measurement two sitting and one standing bp averaged also figured orthostatics and did self report. Covariates/potential confounders adjusted for in analyses: Age, Sex, education, presence of apoE4, use of antihypertensive meds. Method(s) of assessing cognitive status: NINCDS-ADRDA Other: change in performance on cognitive tests over time Informant interview?: No | 1) Follow-up rate: 98% did at least one follow up. 98% of possible clinical evaluations done also. (23 died before first f/u; 47 recent enrollees and not due for annual f/u) 2) Important baseline differences: bp analyzed as a continuous variable so didn’t really compare two groups. 3) Outcome of interest #1 151 incident cases of AD In a fully adjusted model (presence of apoE4, use of antihypertensive meds), a “null relationship persisted” but results not shown. In age, sex and education adjusted model, the relative risk of 1 mmHg increase in sbp was 0.995 (0.986–1.004) and for dbp 1.0 (0.985–1.015) Further analyses, using history of HTN, quadratic terms for SBP and DBP, JNC VII categories of HTN, and sitting BP only, there was no association with incident AD 4) Outcome of interest #2 Again when examining cognitive decline, in a fully adjusted model “the null relationship persisted” but results are not shown. In evaluation using covariates for age, sex, education, sbp x time had estimate of 0.00 with SE 0.00 and p =0.237, dbp x time had estimate 0.000 with SE 0.001 and p = 0.232. time itself had decrease of 0.036 points per year in global score. | Comments: Questions 1 and 2 Probable selection bias: BP measured in older adults w/o dementia; If HTN a risk factor, those with longstanding HTN may have died prior to cohort assembly Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Partial 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Partial 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Partial 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Shumaker, Legault, Kuller, et al., 2004 Women’s Health Initiative Memory Study (WHIMS) | Geographical location: North America Setting: Clinical Study design: RCT Test intervention: CEE (0.625mg) OR CEE + MPA (2mg) Comparator interventions: Matching placebo Number of participants enrolled: 2947 in estrogen- alone trial 4532 in estrogen plus progestin trial Duration of follow up: 4.05 (1.19) Time from risk factor assessment to final cognitive assessment: 4.05 (1.19) | Age: Range: 65 – 79 years Sex: [n (%)] Female: 7479 (100%) Male: 0 (0%) Race/ethnicity: [n (%)] White, non-white; overall statistics not reported Baseline cognitive status: Non-demented Inclusion criteria: Participating in WHIMS study Exclusion criteria: Probable dementia | Risk factor/exposure 1: CEE or matching placebo Also combined data with CEE + MPA trial Method of assessing risk factor/exposure 1: Other – RCT Risk factor/exposure 2: CEE + MPA or matching placebo Method of assessing risk factor/exposure 2: other – RCT Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Smoking Self report cardiovascular dx Hypertension Diabetes Prior HRT or unopposed estrogen therapy Statin use Aspirin use Baseline cognitive status: Method(s) of assessing cognitive status: DSM- IV for dementia. Plus blinded adjudicators. Other – MCI operationally defined as 10^th^ percentile or lower on 1 or more cerad tests and a report of some fct impairment, but not enough to interfere with basic adls (eating dressing grooming) from informant Informant interview?: Yes for individuals with cognitive impairment | 1) Follow-up rate: At year 6 CEE alone 539 of 1464 (36.8%) Placebo 518 of 1483 (34.9%) CEE or CEE+MPA 550 of 3693 (14.9%) Or total placebo 539 of 3786 (14.2%) Adherence at year 6 was 42% for HRT and 47.8% for placebo. 2) Important baseline differences: Higher prevalence of hypertension in CEE group (p=.01) Comparing CEE alone vs CEE + MPA: women receiving CEE alone were less educated, had lower baseline 3MSE scores, more ethnically diverse, more likely to have hx of stroke or coronary heart disease and to have used hrt previously (p<.001 for all) 3) Outcome of interest #1 Classification of alzheimer’s disease By treatment assignment CEE: 13 of 28 dementias were AD Placebo: 9 of 19 dementias were AD CEE+MPA: 20 of 40 dementias dx as AD Placebo: 12 of 21 dementias dx as AD. Combined HRT trials HRT 33 of 68 Placebo 21 of 40 4) Outcome of interest #2 Classification of MCI by treatment CEE: 76 Placebo: 58 HR 1.34 (95% CI 0.97–1.60) In combined CEE and CEE + MPA trial the risks were similar HR 1.25 95% CI 0.97–1.60 5) Outcome of interest #3 Total dementia: CEE HR 1.49 (0.83–2.66) Rate per 10,000 person-years CEE + MPA HR 2.05 (1.21–3.48) Rate per 10,000 person-years Combined 1.76 (1.19–2.60) Rate per 10,000 person-years | Comments: For 13 models bonferroni correction was used to control for type 1 errors P=.05/13= .004- used for total dementia not ad For analyses other than the 13 models a significance level of 0.05 was used. Endpoint was total dementia with AD causing 47% plus 19% mixed dementia. Quality assessment: For RCTs: 1) Baseline comparability? Partial. Some differences- see differences above 2) Valid AD/cognitive outcomes assessment? Yes 3) Subjects/providers blind? Yes 4) Outcome assessors blind? Yes 5) Incomplete data adequately addressed? Yes 6) Differential dropout rate < 10%? Yes 7) Overall dropout rate < 30%? No 8) Conflict of interest reported and insignificant? Yes 9) Randomization adequate? Yes 10) Allocation concealment adequate? Yes
Shumaker, Legault, Rapp, et al., 2003 WHIMS | Geographical location: 39 WHI Centers in the US Setting: Clinical Study design: RCT Test intervention 1 daily tablet of .625mg of conjugated equine estorogen plus 2.5 mg of medroxyprogesterone acetate Comparator intervention(s) Matching placebo Number of participants enrolled: 4532 Duration of follow up: 4.05 (1.19) years Time from risk factor assessment to final cognitive assessment: 4.05 (1.19) years | Age: Range: 65 + Sex: [n (%)] Female: 4352 (100%) Male: 0 (0%) Race/ethnicity: [n (%)]NR Baseline cognitive status: Non-demented Inclusion criteria: Post menopausal Free of probable dementia Age 65 or older Exclusion criteria: 64 or younger Male Pre-menopausal Probable dementia | Risk factor/exposure 1: CEE 0.625mg + MPA 2.5 mg vs placebo Method of assessing risk factor/exposure 1: RCT pill count Covariates/potential confounders adjusted for in analyses: not varied for MCI or AD Method(s) of assessing cognitive status: DSM IV DSM- IV for dementia. Plus blinded adjudicators. MCI operationally defined as 10^th^ percentile or lower on 1 or more cerad tests and a report of some fct impairment, but not enough to interfere with basic adls (eating dressing grooming) from informant Informant interview?: Yes | 1) Follow-up rate: CEE + MPA at 5 years 408/2229= 18.3% Placebo at 5 years 479/2303= 20.8% Adherence rates were lower for each year in CEE+MPA compared to placebo (p<.001) 2) Important baseline differences: Slightly lower prevalence of stroke (p=.01) and higher prevalence of statins (p=.02) in the CEE + MPA group. 3) Outcome of interest #1 CEE+MPA: 20 of 40 dementias dx as AD Placebo: 12 of 21 dementias dx as AD. Reported in shumaker 2004, #2491 and in evidence table for #2491 HR 2.05 (1.21–3.48) for total dementia Rate per 10,000 person- years. 4) Outcome of interest #2 MCI CEE +MPA 56 of 2229 f/u mean 3.99 (SD 1.23) rate/10000 person years 63 Placebo 55 of 2303 f/u mean 4.04 (SD 1.20) rate/10 000 person years 59 HR 1.07 (0.74–1.55) | Comments: None Quality assessment: For RCTs: 1) Baseline comparability? Yes Slight differences listed 2) Valid AD/cognitive outcomes assessment? Yes 3) Subjects/providers blind? Yes 4) Outcome assessors blind? Yes 5) Incomplete data adequately addressed? Yes 6) Differential dropout rate < 10%? Yes 7) Overall dropout rate < 30%? No, not at 5 years 8) Conflict of interest reported and insignificant? Yes 9) Randomization adequate? Yes 10) Allocation concealment adequate? Yes
Skoog, Lithell, Hansson, et al., 2005 Study on Cognition and Prognosis in the Elderly (SCOPE) | Geographical location: Not specified; SCOPE was in 15 countries Setting: Clinical Study design: RCT Test intervention : Candesartan 8–16mg daily; other antihypertensives allowed Comparator intervention(s): Placebo; other antihypertensives allowed Number of participants enrolled: 4937 Duration of follow up: 3.7 yrs range 3 – 5 yrs Time from risk factor assessment to final cognitive assessment: mean=3.7 years | Age: Range: 70 – 89 years Sex: [n (%)] NR Race/ethnicity: [n (%)]NR Baseline cognitive status: mmse ≥ 24 Inclusion criteria: 70 – 89 years Mild to moderate hypertension MMSE score ≥ 24 Exclusion criteria: Secondary hypertension Stroke MI within 6 months Serious concomitant diseases affecting survival Dementia | Risk factor/exposure 1: antihypertensive candesarten (ace i) Method of assessing risk factor/exposure 1: Direct measurement Covariates/potential confounders adjusted for in analyses: country and Baseline cognitive status Method(s) of assessing cognitive status: change in mmse as continuous measure and as categorical outcomes (>=4 point decline) Informant interview?: No | 1) Follow-up rate: can’t tell. 2) Important baseline differences: candesartin vs placebo “similar”, those with “low” mmse had lower education, were older, more women, more hx cva, more dm, 3) Outcome of interest #1 the risk of cognitive decline did not differ between candesartan and placebo (rates not given for participants by intervention). Subgroup analysis: Low cognitive function (baseline MMSE 24–28): candesartan 6.1% vs. placebo 7.0%; p=NS) High cognitive function (baseline MMSE 28–30): candesartan 3.5% vs. placebo 3.7%; p=NS) 4) Outcome of interest #2 In the low mmse group, the mmse score declined less with candesartan than with placebo (mean difference 0.49, (95% CI 0.02 – 0.97) In the high cognitive function group, there was no difference in rate of MMSE decline (−0.8 candesartan vs. −0.73 placebo, p>0.20) | Comments: We were unable to confirm the criteria used for their dementia dx. “Information on sxs in pts who developed suspected dementia or signif cognitive decline was reported on a special form” For scope overall, hctz was added to 49% of candesartan group and 66% of the control group. Target BP <160/90 Quality Assessment: For RCTs: 1) Baseline comparability? Yes 2) Valid AD/cognitive outcomes assessment? Partial 3) Subjects/providers blind? Can’t Tell 4) Outcome assessors blind? Can’t Tell 5) Incomplete data adequately addressed? No 6) Differential dropout rate < 10%? Can’t Tell 7) Overall dropout rate < 30%? Can’t Tell 8) Conflict of interest reported and insignificant? Can’t Tell 9) Randomization adequate? Yes 10) Allocation concealment adequate? Yes
Slooter, Cruts, Hofman, et al., 2004 | Geographical location: Rotterdam Setting: Community Study design Prospective cohort Number of participants enrolled: 6,852 Duration of follow up: 4 years Time from risk factor assessment to final cognitive assessment: Not stated when APOE genotyping was done | Age: Mean (SD): Reported by genotype with means ranging from 67.9 to 72.2 Sex: [n (%)] Female: 59.8 Male: 40.2 Race/ethnicity: [n (%)]100% Caucasian Baseline cognitive status: Dementia present in 351 subjects at baseline= 5.1% population Inclusion criteria: Age >55 living in Rotterdam Exclusion criteria: NR | Risk factor/exposure 1: APOE genotype Method of assessing risk factor/exposure 1: Direct measurement Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Method(s) of assessing cognitive status: NINCDS-ADRDA DSM III-R Informant interview?: Yes | 1) Follow-up rate: 6852/7983= 85.8% 1131 (14%) of cohort could not be genotyped. 2) Important baseline differences: Increased prevalent dementia (12 vs 3%) and younger age (67.9 (8.0) vs 69.9 (9.4))in 4/4 compared to 3/3 3) Outcome of interest #1 Relative Risk of AD by genotype AD n = 256 RR (95% CI) p values compared to E3/3 E2/2 = 1.0 (0.2 to 3.9) E2/3 = 0.5 (0.3 to 0.9) p<.05 E2/4 = 2.4 (1.3 to 4.4) p<.005 E3/3 = 1 (reference) E3/4 = 2.2 (1.6 to 2.9) p<.005 E4/4 = 7.0 (4.1 to 11.9) p<.005 | Comments: 5.1% of subjects had prevalent dementia at baseline, but subjects with prevalent dementia at baseline were excluded from analysis of the association of APOE on dementia Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Smith, Clark, Nutt, et al., 1999 | Geographical location: United Kingdom Setting: Community – recruited with advertisements Study design: RCT Test intervention: 2 mg beta carotene, 400 mg alpha - tocopherol and 500 mg/ascorbic acid daily Comparator intervention(s): placebo Number of participants enrolled: 205 Duration of follow up: 1 year Time from risk factor assessment to final cognitive assessment: 1 year | Age: Mean (SD): Placebo: 66.9 (0.56) Vitamin: 66.8(0.48) Sex: [n (%)] Female: 110 (54) Male: 95 (46) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented (at least not profoundly demented) Inclusion criteria: The inclusion criteria were: aged between 60 and 80 years and within two standard deviations of the normal weight for height, age and sex; no history or evidence of significant disease or mental illness; able and willing to give informed consent; capable of taking 80±120 per cent of the prescribed number of capsules during the run-in period (subjects were given 70 placebo capsules and told to take two daily for a period of 4 weeks. Compliance was considered acceptable if they took between 45 and 67 capsules). Exclusion criteria: Exclusion criteria were: current medication likely to influence the outcome measures; use of vitamin supplements in the preceding 3 months; evidence or history of regular or chronic drug abuse including alcohol; significant cardiovascular, respiratory, hepatic, renal, gastrointestinal, endocrine, neurological disease or abnormality; malabsorption syndrome; psychiatric disorder; subjects unable or unwilling to give informed consent; disorders which would interfere with the understanding or compliance with the study, hypersensitivity to any of constituents in the active treatment; MMSE score < 18; participation in another drug clinical trial within the previous 6 months; subjects from whom blood samples could not be obtained. | Risk factor/exposure 1: vitamin Method of assessing risk factor/exposure 1: Self-report Direct measurement Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Vegetable/fruit consumption; alcohol consumption; smoking; somatic symptoms; levels of other anti- oxidants Method(s) of assessing cognitive status: Other – change on cognitive measures Informant interview?: No | 1) Follow-up rate: Not specifically reported but appears to be 185/205 [JIA SR reported that placebo group 16.% % dropped out and vitamin group 2.1 dropped out.] 2) Important baseline differences: No significant differences 3) Outcome of interest #1 Number of significant findings on all cognitive measures did not exceed the number one would expect to find by chance (4/117 significant). Did not give significance level. | Comments: None Quality assessment: For RCTs: 1) Baseline comparability? Yes 2) Valid AD/cognitive outcomes assessment? Yes 3) Subjects/providers blind? Can’t Tell 4) Outcome assessors blind? Can’t Tell 5) Incomplete data adequately addressed? Can’t Tell 6) Differential dropout rate < 10%? No 7) Overall dropout rate < 30%? Yes 8) Conflict of interest reported and insignificant? Can’t Tell 9) Randomization adequate? Can’t Tell 10) Allocation concealment adequate? Can’t Tell
Solfrizzi, D’Introno, Colacicco, et al., 2007 Italian Longitudinal Study on Aging (ILSA) | Geographical location: 8 Italian municipalities Setting: Community-includes residents of institutions Study design: Prospective cohort Number of participants enrolled: 1566 analytical sample Duration of follow up: 3.5 yr Time from risk factor assessment to final cognitive assessment: 3.5 yr | Age: Mean (SD): 73.4 (5.6) Sex: Female: 1374 (43.6%) Male: 1589 (56.4) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented but some had MCI Inclusion criteria: Aged 65 to 84 residing in 8 Italian municipalities Exclusion criteria: Dementia at baseline (excluded from present analyses) | Risk factor/exposure 1: alcohol Method of assessing risk factor/exposure 1: Self-report - amount of beer, wine, ‘shots of spirits’ consumed in previous year. Also asked about life long history of alcohol use. Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Smoking CAD Diabetes Hypertension Stroke cholesterol Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Other – MCI defined by modified Petersen criteria Informant interview?: Yes | 1) Follow-up rate: 2963/4521 completed baseline (226 demented, 1171 ref cognitive tests, 161 education unknown) 1445/2963 with baseline normal cognition completed follow-up 121/139 with MCI completed follow- up 2) Important baseline differences: Statistical comparisons not reported 3) Outcome of interest #1 No significant associations between any levels of drinking and the incidence of MCI in non–cognitively impaired individuals vs abstainers. 4) Outcome of interest #2 MCI moderate drinkers (<1 drink/day) had a lower rate of progression to dementia than abstainers (hazard ratio [HR] 0.15; 95% CI 0.03 to 0.78) MCI moderate drinkers (<1 drink/day) of wine had a lower rate of progression to dementia than abstainers (HR 0.15; 95% CI 0.03 to 0.77). No significant association between higher levels of drinking (≥1 drink/day) and rate of progression to dementia in patients with MCI vs abstainers. | Comments: Q2 only Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Partial 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? No 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Solfrizzi, Panza, Colacicco, et al., 2004 Italian Longitudinal Study on Aging (ILSA) | Geographical location: 8 Italian Municipalities: Genoa, Segrate (Milan), Selvazzano- Rubano (Padua), Impruneta (Florence), Fermo (Ascoli-Piceno), Naples, Casamassima (Bari), and Catania Setting: Community (but also includes nursing homes). Study design: Prospective cohort Number of participants enrolled: 2963 (they seem to have used different pools of subjects for different risk factors (e.g., some risk factors required laboratory work and thus had a smaller n) Duration of follow up: 3.5 yrs Time from risk factor assessment to final cognitive assessment: 3.5 yr | Age: Range: 65 – 84 Sex: [n (%)] Female: 1373 (46.3%) Male: 1590 (53.7%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Normal MCI Inclusion criteria: Independent or institutionalized; on electoral rolls of stated municipalities; each site was stratified by gender and age Exclusion criteria: Brain tumors, cerebrovascular malformations, psychosis, epilepsy, MS, stage III syphilis, dementia and any active neuropsychiatric condition producing disability, subjects taking neuroleptics | Risk factor/exposure 1: smoking Method of assessing risk factor/exposure 1: Smoking by self-report Risk factor/exposure 2: Diabetes Method of assessing risk factor/exposure 2: self report or hyperglycemia on blood work and confirmed with medical records and subject’s physician. Risk factor/exposure 3: HTN Method of assessing risk factor/exposure 3: self report, direct measurement, medical records Covariates/potential confounders adjusted for in analyses: Age Educational level Total cholesterol HTN Coronary artery disease Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Other – variation of Petersen’s criteria for MCI Informant interview?: Yes | 1) Follow-up rate: 2963/ 4134 (the difference in these numbers are those who were excluded from study because they refused cognitive screening test). It is not the best measure of follow-up rate but only one provided. 2) Important baseline differences: NR 3) Outcome of interest #1 Number of pack-years of smoking not associated with risk of incident MCI in multi-variate models 4) Outcome of interest #2 Ever vs never smoking did not alter risk of progression from MCI to dementia | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Partial 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Partial
Staehelin, Perrig- Chiello, Mitrache, et al., 1999 Basel IDA | Geographical location: Basel, Switzerland Setting: Community Study design: Prospective cohort Number of participants enrolled: 332 Duration of follow up: 2 years Time from risk factor assessment to final cognitive assessment: APOE genotype obtained at second assessment | Age: Mean (SD): young old 71.43 years ( 115 men and 72 women Old-old mean age 82.58 years (112 men and 33 women) Sex: [n (%)] Female: 31.6 Male: 68.4 Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: A randomly selected subsample of the Basel IDA Exclusion criteria: NR | Risk factor/exposure 1: APOE Method of assessing risk factor/exposure 1: Direct measurement Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Lipids Smoking Method(s) of assessing cognitive status: Other – computerized test for free recall (FR), and information processing speed. Recall consists of describing all the elements of a scene that the subject can remember. Reaction time (RT) was assessed by responding to flashing suns on screen. WAIS-R vocabulary test (WVT)- define 32 words Informant interview?: No | 1) Follow-up rate: 442 subjects randomly identified. 332 have full data. 110 dropped out due to death, ill health, changed mind about participating. 332/442= 75.1% 2) Important baseline differences: Subjects who completed study are likely to be in better health than those who did not complete study. 3) Outcome of interest #1 No significant changes in any outcome measure (FR, RT and WVT) after 2 years. 4) Outcome of interest #2 At baseline: Adjusting for age and education: E4/4 and E3/4 performed lowest in FR, RT and WVT compared to E3/3 or carriers of one or two E2 alleles (FR P=.05; RT P=.009; WVLT P<.05) | Comments: Study is limited by small sample size and 2 year follow-up. Subjects with E4 allele performed more poorly at baseline on FR, RT and WVLT. No significant change in any outcome measure was found over two year follow-up. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Partial 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Stott, Falconer, Kerr, et al., 2008 PROSPER (Prospective Study of Pravastatin in the Elderly Risk) | Geographical location: Ireland, the Netherlands, and Scotland Setting: Community-based (2nd-dary analyses of RCT data) Study design: Prospective cohort approach for secondary analyses of RCT Number of participants enrolled: 5804 Duration of follow up: Mean = 3.2 yr Time from risk factor assessment to final cognitive assessment: Mean = 3.2 yr | Age: Provided by 3 levels of exposure and gender. Means ranged from 74.7 – 75.8 (sd ranged 3.2–3.4) Sex: Female: 3000 (51.7%) Male: 2804 (48.3%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented – (assume most were non-demented because a score of ≥ 24 on the MMSE was required for inclusion) Inclusion criteria: Participant in PROSPER RCT, aged 70–82 with vascular risk factors or vascular disease, baseline MMSE >24 points Exclusion criteria: None except as covered by inclusion criteria. | Risk factor/exposure 1: Alcohol Method of assessing risk factor/exposure 1: Self-report – usual intake in units per week during previous month Covariates/potential confounders adjusted for in analyses: Age Country Educational level Baseline cognitive status Smoking status BMI Weight Incident stroke History of vascular disease Test version Method(s) of assessing cognitive status: Other – longitudinal performance on MMSE, Stroop Color-Word test, Letter-Digit Coding test, Picture-Word Recall test. Informant interview?: No | 1) Follow-up rate: NR 2) Important baseline differences: Compared to nondrinkers, drinkers were slightly younger, had more yrs of education, more likely to smoke, less likely to have history of vascular disease or diabetes, were taller, had lower BMI, had higher HDL-C and lower triglycerides. Greater proportion of drinkers in the Netherlands than in Scotland or Ireland. 3) Outcome of interest #1 Rate of cognitive decline was similar for drinkers and nondrinkers for all cognitive domains, except the MMSE, which declined significantly less in female drinkers compared to nondrinkers (attenuated rate of decline = 0.05 MMSE units per annum, p=0.001) | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Partial 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Partial 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Can’t Tell 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Sturman, de Leon, Bienias, et al., 2008 CHAP | Geographical location: Chicago (south side), US. Setting: Community Study design: Prospective cohort Number of participants enrolled: 3,885 out of 6185 participants who were originally enrolled. Duration of follow up: 6 Yrs Time from risk factor assessment to final cognitive assessment: 6 Yrs | Age: Mean (SD): 73.8 Range: 65–85+ Sex: [n (%)] Female: 2369 (60.97%) Male: 1516 (39.02%) Race/ethnicity: [n (%)] Black : 2371 (61%) Non-Black: 1514 (39%) Baseline cognitive status: Per the methods papers, detailed cognitive testing done on all. However, AD not mentioned as exclusion criteria in this study. In further analysis of the initial model, participants whose MMSE was less than 24 were excluded. Inclusion criteria: Resident of three neighborhoods in Chicago: Morgan Park, Beverly, and Washington Heights Exclusion criteria: Body mass index (BMI kg/m2) outside a range of15 and 50 | Risk factor/exposure 1: BMI (Body Mass Index) Method of assessing risk factor/exposure 1: Direct measurement Risk factor/exposure 2: Chronic medical conditions including hypertension, heart disease, diabetes and stroke. Method of assessing risk factor/exposure 2: Self-report Direct measurement Medication records. Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Hypertension Heart disease, Diabetes and Stroke Method(s) of assessing cognitive status: NINCDS-ADRDA DSM ICD Other Informant interview?: No | 1) Follow-up rate: 63.09% (3885 out of 6158 residents) 569 -missing global cognitive function scores at baseline or had only one global cognitive measurement, 1,139 died before the first follow-up, and 477 had no information on weight or height at baseline 13 participants had Body mass index (BMI kg/m2) outside a range of15 and 50 2) Important baseline differences: Unable to determine specifically. From text: Individuals with high BMIs were more likely to be young, female and black with higher incidences of chronic illnesses. 3) Outcome of interest #1 Association of categories of body mass index (BMI) (kg/m2) relative to normal weight with global cognitive scores over time after adjusting for age (years, centered at 75), sex, education (years, centered at 12 years), and the time on study (years since baseline) Underweight x time for Black participants: Coefficient 0.0164 p value 0.379 Underweight x time for non black participants: Coefficient 0.0512 p value 0.011 Overweight x time for Black participants: Coefficient 0.0012 p value 0.849 Overweight x time for Non Black participants: Coefficient 0.0102 p value 0.191 Obese x time for Black participants: Coefficient 0.0072 p value 0.275 Overweight x time for Non Black participants: Coefficient 0.0119 p value 0.234 [ Note: above sample had participants with all levels of cognitive functioning) 4) Outcome of interest #2 Association of body mass index (BMI) (kg/m2) with global cognitive scores over time among participants with Mini-Mental State Examination (MMSE) score greater than or equal to 24: BMI X time for black participants: Coefficient 0.0003 p value 0.415 BMI X time for Non Black participants: Coefficient 0.0008 p value 0.086 | Comments: The main sample consists of participants with all levels of cognitive performance. From the methods papers, 543 patients were classified as intermediate or poor cognitive functioning out of which 152 patients had confirmed AD. They were not excluded. However, they do make an effort to exclude those whose MMSE is less than 24 in one analysis. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? No 8) Adequate follow-up period? Yes 9) Completeness of follow-up? No 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Can’t Tell
Swan, DeCarli, Miller, et al., 1998 NHLB Institute Twin Study | Geographical location: USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 1028 at baseline for larger study; 392 available for analysis in this sub-study Duration of follow up: baseline 1969–1972, cv followups 79–80 and 85–86 (and first cognitive) and 95–97 Time from risk factor assessment to final cognitive assessment: Bp’s checked waves 1–3, cognitive 85–86 and 95–97 | Age: Range: 68 – 79 years Sex: Male: 100% Race/ethnicity: White 100% Baseline cognitive status: doesn’t really say, but baseline age was 46–47 Inclusion criteria: Participating in the NHLBI Twin Study Exclusion criteria: Ineligible or unwilling to undergo MR imaging | Risk factor/exposure 1: htn Method of assessing risk factor/exposure 1: Direct measurement Mean of bps taken lying, sitting, standing then first three waves averaged Covariates/potential confounders adjusted for in analyses: Age, stroke hx, Educational level Method(s) of assessing cognitive status: change in test scores Informant interview?: No | 1) Follow-up rate: maybe 317/392, 70.9%, not clear 2) Important baseline differences: increasing levels of midlife sbp were associ with age, incid cvd, chd and prevalent pad, antihypertensives associ with sbp 3) Outcome of interest #1 Subjects with high midlife sbp experienced a greater decline than those with low sbp (<120), 10 year change mmse ±sem low sbp 0.04 ± 0.28, high sbp −0.66 ± 0.36 dss test −1.55 ± 0.69 for low sbp, −5.03 ± 0.84 for high sbp | Comments: largely the same group as Carmelli Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Szekely, Breitner, Fitzpatrick, et al., 2008 Cardiovascular Health Cognition Study (CHCS – sub-group of CHS) | Geographical location: Sacramento, County, CA Washington County, MD Forsyth County, NC Allegheny County, PA Setting: Community Study design: Prospective cohort Number of participants enrolled: 3229 Duration of follow up: annually up to 10 years Time from risk factor assessment to final cognitive assessment: both assessment and rf done 1992–4 and annually | Age: Range: ≤75 yo 1631 (51%) > 75 yo 1598 (49%) Sex: [n (%)] Female: 1931 (59.8%) Male: 1298 (40.2%) Race/ethnicity: [n (%)] African American 471 (14.6%) White 2743 (84.9%) Other 15 (0.5%) Baseline cognitive status: Not demented Inclusion criteria: Participation in Cardiovascular Health Cognition Study; ≥ 65 yo; free of dementia @ baseline; info available for Rx and OTC medications Exclusion criteria: NR | Risk factor/exposure 1: nsaids Method of assessing risk factor/exposure 1: examined pill bottles Covariates/potential confounders adjusted for in analyses: Age Sex, Education, E4, baseline 3MS Educational level Baseline cognitive status Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Informant interview?: Yes- the majority of the living had an informant; multiple approaches used for living and deceased individuals | 1) Follow-up rate: This includes 3,229 subjects who were not demented in 1992–1994 visit. Not clear how many were followed for how long. 2) Important baseline differences: nsaid users: more women, younger, more arthritis. 3) Outcome of interest #1 HR with nsaids 0.62 (0.44–0.88) 4) Outcome of interest #2 no ‘greater reduction’ (assume means still was a significant reduction) in HR with lagging of exposure, longer use, higher doses – These are the results we need to use, but actual HR not given for these 5) Outcome of interest #3 possibly only reduced if e4 POSITIVE HR 0.34 (0.18–0.65) | Comments: The results we used are those that were limited to exposure being at least 1–2 years prior to outcome. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Partial 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Can’t Tell 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Partial
Szwast, Hendrie, Lane, et al., 2007 Indianapolis Ibadan Dementia Project | Geographical location: Indianapolis, IN Setting: Community Study design: Prospective cohort Number of participants enrolled: 2519 Duration of follow up: 3 yrs Time from risk factor assessment to final cognitive assessment: 0 to 3 yrs | Age: Mean (SD): 77.3 (5.3) Sex: Female: 791 (69.3%) Male: 350 (30.7%) Race/ethnicity: African American 1146 (100%) Baseline cognitive status: Non-demented Inclusion criteria: 1992 sample: African American; ≥ 65 yo 2001 sample: African American; ≥ 70 yo; Medicare beneficiary Exclusion criteria: No ApoE results at baseline; dementia | Risk factor/exposure 1: Statin use (simvastatin, atorvastatin, pravastatin, fluvastatin, cerivastatin, lovastatin), medical history, smoking, alcohol use, social involvement Method of assessing risk factor/exposure 1: Self-report Direct measurement – for statins: medication bottles or printed lists from pt’s Dr at baseline Risk factor/exposure 2: BP, height, weight, ApoE, lipids Method of assessing risk factor/exposure2: Direct measurement Covariates/potential confounders adjusted for in analyses: Age, sex, years of educations, statin use at baseline, Any Apoe E4 allele Method(s) of assessing cognitive status: Other – Community Screening Interview for Dementia (0–34 with higher scores indicating better cognitive function) Informant interview?: Yes- They used the CAMDEX | 1) Follow-up rate: 1146 of 1808 with ApoE data (63.1%) 2) Important baseline differences: The statin and non statin users differed significantly in the following: Age at baseline, BMI at baseline, h/o hypertension, h/o stroke, h/o diabetes, h/o heart disease, cholesterol level >300 mg/dl, LDL-C>130, use of NSAIDS, use of antipatelet medication/asprin. Baseline: 284 on statin only, 3 on statin + other lipid lowering agent Statin use at baseline 3) Continuous outcome [for each such outcome, please report the following information wherever possible for the exposed/intervention group and the unexposed/control group: - N, mean value and SD at baseline - N, mean value, and SD at follow up, and/or the N and mean change and SD of the change. If these values are not given, abstract whatever is reported.] 287 on statins, 854 non-statin 1. Analysis of covariance, adjusting for age, gender, education, ApoE e4 allele. Cognitive decline = CSI-D scores at baseline minus 3-year f/u score standardized to effect sizes. Parameter estimate (Value > 0 indicates cognitive decline), SE, p value Female: 0.02, 0.06, p=0.7489 Education(years): −0.02, 0.01, p=0.1668 ApoEe4: 0.15, 0.06, p=0.0149 Baseline statin: −0.16, 0.07, p=0.0177 Adjustment for baseline cognitive score, statins associated with less cognitive decline (only p value given, p=0.0046) 2. Analysis of covariance, adjusting for age, gender, education, ApoE e4 allele. Cognitive decline = CSI-D scores at baseline minus f/u score standardized to effect sizes. Parameter estimate (Value > 0 indicates cognitive decline), SE, p value Female: 0.03, 0.06, p=0.6076 Education(years): −0.02, 0.01, p=0.1708 ApoEe4: 0.16, 0.06, p=0.0115 Baseline statin only: −0.28, 0.12, p=0.0217 Statin at 3 year f/u only: 0.04, 0.10, p=0.6765 Statin at baseline and f/u: −0.12, 0.08, p=0.1258 | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Partial 3) Sample size calculated/5%difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Partial 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Can’t Tell 9) Completeness of follow-up? No 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Tang, Cross, Andrews, et al., 2001 WHICAP | Geographical location: Manhattan, NY, USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 1788 Duration of follow up: Mean 4.3 yrs SD1.4 (Caribbean Hispanic; 1.5 white and AA) Time from risk factor assessment to final cognitive assessment: Mean 4.3 yrs SD1.4 (Caribbean Hispanic; 1.5 white and AA) | Age: Mean (SD): AA 75.8 (6.2); Caribbean Hispanic 74.9 (5.8); white 76.9 (7.2) Sex: [n (%)] Female: 224 (12.5%) Male: 1564 (87.5%) Race/ethnicity: [n (%)] Caribbean Hispanic: 42.5% AA: 34.1% White: 23.4% Baseline cognitive status: Non-demented Inclusion criteria: Random sample from 3 contiguous zip codes within Washington Heights, NY, aged ≥ 65 yrs old Current analyses included subset with baseline and longitudinal follow-up Exclusion criteria: Dementia | Risk factor/exposure 1: Diabetes mellitus Method of assessing risk factor/exposure 1: medical history, medication Risk factor/exposure 2: Stroke, heart disease, hypertension Method of assessing risk factor/exposure 2: Self-report Medical history Other –use of medication Covariates/potential confounders adjusted for in analyses: Age Sex Educational level APOE Diabetes BMI Hypertension Heart disease Stroke Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Other – cognitive change within cognitive domain. Used analytical method that controls for baseline score (tests combined based on factors analyses) Informant interview?: No | 1) Follow-up rate: 1788/2126 =84.1% 2) Important baseline differences: Whites were older (p=.001) and had more years of education (p=.001) than AA or Caribbean Hispanics. AA had more education than Caribbean Hispanics (p=.001). AA and Caribbean Hispanics had more diabetes than whites (p=.01). Heart disease was more frequent in Caribbean Hispanics than AAs(p=.001). 3) Outcome of interest #1 HR developing possible or probable AD in participants with diabetes 1.6(95% CI 1.1–2.3) (p ≤ 0.01) 4) Outcome of interest #2 Stroke HR 0.9 (95% CI 0.5–1.6) 5) Outcome of interest #3 Hypertension HR 1.4 (95% CI 0.9–1.9) | Comments: Question 1 Diabetes mellitus was associated with a significantly increased risk of incident AD (probable or possible in this multi-racial, multi-ethnic population. Hypertension, stroke and heart disease were not significantly associated with incident possible or probable AD. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5%difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Tervo, Kivipelto, Hanninen, et al., 2004 | Geographical location: Kuopio, Finland Setting: Community Other-nursing facilities Study design: Prospective cohort Number of participants enrolled: Random sample screened: 1,150; 747 enrolled subjects Duration of follow up: 3.26 +/− 0.70 yrs Time from risk factor assessment to final cognitive assessment: 3.25 +/− 0.72 yrs | Age: Range: 60–76 yrs Sex Female: 454 (61%) Male: 293 (39%) Race/ethnicity: NR Baseline cognitive status: Non-demented Inclusion criteria: 60 yrs and older, non- demented; no evidence MCI Exclusion criteria: NR | Risk factor/exposure 1: Education, years Method of assessing risk factor/exposure 1 Self-report Risk factor/exposure 2: ApoE4 allele Method of assessing risk factor/exposure 2 Direct measurement Risk factor/exposure 3: Diabetes mellitus (included diet, tablet or insulin-treated) Method of assessing risk factor/exposure 3 Self report Risk factor/exposure 4: Elevated blood pressure: HTN=SBP160 mm Hg or greater or DBP 95 mm Hg or greater. Method of assessing risk factor/exposure 4 Direct measurement Risk factor/exposure 5: Medicated hypertension Method of assessing risk factor/exposure 5 Self report Covariates/potential confounders adjusted for in analyses Age Race Sex Educational level Baseline cognitive status Method(s) of assessing cognitive status: NINCDS-ADRDA DSM-IV Other –CERAD; Clinical Dementia Rating (CDR):MCI diagnosed if score of0.5 and if subject scored 1.5 SD below average on at least one memory test. Informant interview?: No | 1) Follow-up rate: Random sample of 1150 subjects. 806 evaluated. 747 eligible. F/u: 550/747(77.7%) 2) Important baseline differences: NA 3) Outcome of interest #1—Education OR (95% CI) 0.80 (0.71–0.90) 4) Outcome of interest #2--APOE OR (95% CI) 2.23(1.23–4.05) 5) Outcome of interest #3-- Diabetes OR (95% CI) 1.55(0.58–4.19) 6) Outcome of interest #4—High blood pressure (DBP≥95 or SBP>160) OR (95% CI) 0.91(0.49–1.69) 7) Outcome of interest #5— Medicated HTN OR (95% CI) 1.61(0.87–2.99) Results: 66 subjects (8.8%) had converted to MCI. The global incidence rate of MCI was 25.94/1,000 person-years. Persons with ApoE4 allele and medicated hypertension were more likely to convert to MCI. High education is a protective factor for MCI | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5%difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Thal, Ferris, Kirby, et al., 2005 | Geographical location: 46 US sites Setting: Other – clinical and community: combination of patients identified by investigators and volunteers responding to an ad about RCT – Study design: RCT Test intervention: Rofecoxib 25 mg Comparator intervention(s): placebo Number of participants enrolled: 1457 Duration of follow up: 115 weeks rofecoxib, 130 weeks placebo Time from risk factor assessment to final cognitive assessment: q4mos:cdr, mmse, srt, q12mos ADAS-Cog Time from 1^st^ to last cognitive assessment =48 mos | Age: Mean (SD): Placebo = 74.8 (6.0) Drug = 75.1 (6.0) Sex: [n (%)] Female: 477 (32.7%) Male: 980 (67.3%) Race/ethnicity: [n (%)] NR Baseline cognitive status: MCI Inclusion criteria: ≥65 yo; at least 8grades of education; had a reliable informant who could accompany them to each visit; pt or informant reported memory problem; memory has declined in last yr; MMSE ≥ 24; CDR global score = 0.5 with memory domain score ≥ 0.5; BDRS total score ≤ 3.5 with no part 1 item score >0.5; AVLT total score ≤ 37 Exclusion criteria: Dementia; inadequate motor or sensory capacities to comply with testing; a modified Hachinski Ischemic Scale score > 4; Hamilton Depression Scale (17-item version) score > 13; history of angina or CHF with symptoms that occurred at rest; uncontrolled HTN; history within past yr of MI; coronary artery bypass, angioplasty, or stent placement; history within past 2 yrs of stroke, multiple lacunar infarcts, or transient ischemic events; history within past 3 months of GI bleeding; and expected therapeutic need for chronic NSAID or estrogen replacement therapy during the study; pts taking NSAIDS on a chronic basis for 2 mos prior to study; estrogen replacement therapy (excluding topical ointments) withint 2 mos of study; cholinesterase inhibitors within 1 mo of study | Risk factor/exposure 1: nsaid Method of assessing risk factor/exposure: rct rofecoxib and placebo Covariates/potential confounders adjusted for in analyses: treatment region, mmse strata (24–26 or>26) Method(s) of assessing cognitive status: NINCDS-ADRDA Other – Dementia determined by CDR ≥ 1 Informant interview?: Yes | 1) Follow-up rate: placebo 45% dc’d, 41% finished rofecoxib 45% dc’d, 40% finished 2) Important baseline differences: not apparent 3) Outcome of interest #1 increased HR for AD with rofecoxib1.46 (1.09–1.94) but a minority finished on drug, and secondary measures did not confirm increased risk (ADAS-Cog, SRT, MMSE, BDRS, CDR sum of boxes) | Comments: Minority finished study (which was terminated early) on drug Quality assessment: For RCTs: 1) Baseline comparability? Yes 2) Valid AD/cognitive outcomes assessment? Yes 3) Subjects/providers blind? Yes 4) Outcome assessors blind? Yes 5) Incomplete data adequately addressed? No 6) Differential dropout rate < 10%? Yes 7) Overall dropout rate < 30%? No 8) Conflict of interest reported and insignificant? Yes 9) Randomization adequate? Yes 10) Allocation concealment adequate? Yes
Tierney, Oh, Moineddin, et al., 2009 | Geographical location: Greater Toronto area Setting: Community Study design RCT Test intervention (RCTs only): Per week 1 mg 17-βestradiol for 4 days, then combo with 0.35 norethindrone for 3days Comparator intervention(s) (RCTs only): placebo Number of participants enrolled: 142 Duration of follow up: 2 year trial Time from risk factor assessment to final cognitive assessment: NR | Age: Mean (SD): 74.8 (6.9) Sex: [n (%)] Female: 142 (100%) Male: 0 (0%) Race/ethnicity: [n (%)] White 132 (93.0 %) Black 6 (4.2%) Asian 4 (2.8%) Baseline cognitive status: Non-demented Inclusion criteria: Age ≥ 60 with last menstrual cycle ≥ 12 months before screening; were fluent in English; could read normal print and hear normal speech. Exclusion criteria: Met criteria for dementia, or had a clinical history of a neurological systemic or psychiatric condition that would affect cognition; women with conditions that were considered at the time of enrollment to be exacerbated by estrogen, including history of breast or endometrial cancer; history of myocardial infarction (MI), coronary artery bypass graft (CABG), angioplasty or unstable angina within the past year; history of congestive heart failure (CHF) (NYHA Class III or IV); or history of thromboembolic event withint the past 6 months; women taking donepezil, galantamine, rivastigmine, hydergine, tamoxifen, or raloxifene, or had used any mode or dose of HT within the past 2 years; women who met neuropsychological criteria for dementia; women who had an identifiable cause of memory disorder (e.g., stroke) or were considered to meet criteria for dementia. | Risk factor/exposure 1: estrogen/progesterone hormone therapy Method of assessing risk factor/exposure 1: meds administered Covariates/potential confounders adjusted for in analyses: Age, education, apoE, prior hormone use Method(s) of assessing cognitive status: NINCDS-ADRDA DSM used to dx dementia per methods but outcome here is cvlt recall Informant interview?: No | 1) Follow-up rate: in active tx group: 70 randomized, 4 dropped out, 1 death, 18 dc’d meds at yr 1, 2 dropped out, 1 died, 8 dc’d meds at yr 2. In the placebo group, 72 randomized, 4 dropped out and 1 died and 12 dc’d tx at yr 1. In yr 2, 1 refused, 1 died, 4 self dc’d 2) Important baseline differences: More apoe4 carriers in placebo group. More prior ht use in tx group. 3) Outcome of interest #1 Group differences on the cvlt short delay verbal recall were not significant at year 1 or 2 4) Outcome of interest #2 For the subgroup scoring average or above at baseline (>7), those on HT had less decline at yr 1 and yr 2 as compared to placebo (p=.007 and p=0.01) 5) Outcome of interest #3 no treatment effect for those scoring below average. | Comments: Question 5 – no cat Dx Primary outcome is ‘short delayed’ recall on CVLT. They don’t give an estimate of how long their short delay is. Quality assessment: For RCTs: 1) Baseline comparability? Yes 2) Valid AD/cognitive outcomes assessment? Yes 3) Subjects/providers blind? Yes 4) Outcome assessors blind? Yes 5) Incomplete data adequately addressed? Yes 6) Differential dropout rate < 10%? Yes 7) Overall dropout rate < 30%? Yes 8) Conflict of interest reported and insignificant? Yes 9) Randomization adequate? Yes 10) Allocation concealment adequate? Yes
Tyas, Salazar, Snowdon, et al., 2007 NUN study | Geographical location: United States Setting: Other – Nuns Study design: Prospective cohort Number of participants enrolled: 1031 initially eligible, 678 agreed to participate, 470 had complete data. Duration of follow up: NR. Annual exams from 1991–2002, so range is probably 1–11 years Time from risk factor assessment to final cognitive assessment: NR. Annual exams from 1991–2002, so range is probably 1–11 years | Age: Mean (SD): 84.3 (5.0) Sex: Female: 470 (100%) Male: 0 (0%) Race/ethnicity: NR Baseline cognitive status: Normal Non-demented MCI CIND AAMI Inclusion criteria: Members of the School Sisters of Notre Dame born before 1917 and living in certain regions of the US. Aged ≥75 yrs. Exclusion criteria: NR | Risk factor/exposure 1: Education 1) ≤ High school 2) Undergrad degree 3) Grad degree (reference) Method of assessing risk factor/exposure 1: Self-report Risk factor/exposure 2: APOE Method of assessing risk factor/exposure 2: Direct measurement Covariates/potential confounders adjusted for in analyses: Age Education APOE Prior cognitive state Method(s) of assessing cognitive status: Cognitive test in the Consortium to Establish a Registry for Alzheimer’s Disease Informant interview?: No | 1) Follow-up rate: 1031 initially eligible. 678 (66%) agreed to participate. Exclusions: missing examinations (n=58), missing APOE data (n=35), dementia at baseline (n=115). Analytic sample: 470/678 (69%) Of the 470, 192 provided data on 6 transitions and all 7 annual exams. 2) Important baseline differences: NA 3) Outcome of interest #1 Transitions/outcomes: 1) intact cognition 2) MCI 3) global impairment 4) death Total of 1905 transitions. From MCI to global impairment: n=110 (11.6%) From MCI to dementia: n=71 (7.5%) 4) Outcome of interest #2 Age, education, and APOE were all significant predictors of transition from intact cognition to mild cognitive impairment. Similar pattern for transition from intact cognition to global impairment. 5) Outcome of interest #3 Transition from intact to MCI, OR (95% CI): 1) Age 1.06 (1.03, 1.09) 2) Education (grad degree as ref.) --≤high school 2.36 (1.26, 4.42) --undergrad 1.53 (1.17, 2.00) 3) APOE present 1.87 (1.27, 2.73) 4) Prior cognitive state (global impairment as ref.) --intact cognition 0.18 (0.09, 0.38) --MCI 1.82 (0.09, 3.68) [underlined: Transition from intact to global impairment], OR (95% CI): 1) Age 1.15 (1.10, 1.20) 2) Education (grad degree as ref.) --≤ high school 2.79 (1.32, 5.91) --undergrad 1.62 (1.10, 2.38) 3) APOE present 3.02 (1.87, 4.89) 4) Prior cognitive state (global impairment as ref.) --intact cognition 0.02 (0.01, 0.03) --MCI 0.11 (0.06, 0.21) | Comments: A variety of transitions of cognitive decline assessed. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5%difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Can’t Tell 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Partial (69%, if include exclusion for dementia at baseline) 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Tzourio, Anderson, Chapman, et al., 2003 Perindopril Protection Against Recurrent Stroke Study (PROGRESS) | Geographical location: 172 centers in 10 countries Setting: Clinical Study design: RCT Test intervention: Perindopril 4mg daily +/− indapamine 2–2.5 mg daily Comparator intervention(s): placebo Number of participants enrolled: 6105 Duration of follow up: Mean = 3.9 years Time from risk factor assessment to final cognitive assessment: Mean = 3.9 years | Age: Mean (SD): 64 (10) years Sex: Female: 30% Male: 70% Race/ethnicity: Asian: 39% Other: 61% Baseline cognitive status: Non-demented and cognitively impaired (15% with MMSE <25) MCI Inclusion criteria: H/o TIA or Stroke w/in 5 years No clear indication for, nor contraindication to treatment with an ACE inhibitor Tolerated and adhered to perindopril during 4-week run-in phase Exclusion criteria: NR | Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Baseline cognitive status Method(s) of assessing cognitive status: MMSE at baseline, 6- and 12-month visit, then annually Cognitive decline defined as >=3 point drop Informant interview?: NA | 1) Follow-up rate: 22% discontinued use of all study tablets (active 23%; placebo 21%) Cognitive decline assessed in 5888 study participants (96.4%) 2) Important baseline differences: No 3) Outcome of interest #1 Cognitive decline = 610 (134 with recurrent stroke, 476 w/o stroke): Active: 276/3051 (9.1%), 23/1000 person years Control: 334/3054 (11.0%), 28/1000 person years RR = 0.81 (95% CI 0.68–0.96) Sensitivity analysis defining cognitive decline as ?=2 or >=4 points did not “materially alter” the results 4) Outcome of interest #2 Change in MMSE (baseline – f/u) Active: 0.05 (0.05 SE) Placebo: 0.24 (0.05 SE) Difference in change (placebo – active): 0.19 (0.07 SE) less decline for active, p=0.01 5) Outcome of interest #3 Mean difference in BP between active and control = 9/4 mm Hg | Comments: Note – no BP criteria for entry, 48% had SBP >=160 or DBP >=90; 50% on antihypertensive medication at baseline Quality assessment: For RCTs: 1) Baseline comparability? Yes 2) Valid AD/cognitive outcomes assessment? Yes 3) Subjects/providers blind? Can’t Tell, probably subjects 4) Outcome assessors blind? Yes 5) Incomplete data adequately addressed? Yes 6) Differential dropout rate < 10%? Yes 7) Overall dropout rate < 30%? Yes 8) Conflict of interest reported and insignificant? Partial; co-funded with Servier Pharmaceutical Company 9) Randomization adequate? Yes 10) Allocation concealment adequate? Yes
Tzourio, Dufouil, Ducimetiere, et al., 1999 EVA | Geographical location: Nantes, France Setting: Community Study design: Prospective cohort Number of participants enrolled: 1,373 Duration of follow up: 4 years Time from risk factor assessment to final cognitive assessment: 2–4 years | Age: Mean (SD): 65 (3.0) Sex: [n (%)] Female: 807 (58.8%) Male: 566 (41.2%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Uncertain, those with cognitive impairment not specifically excluded. Inclusion criteria: Age 59–71 yo Exclusion criteria: Stroke during f/u | Risk factor/exposure 1: HTN : SBP ≥ 160 or DBP ≥ 95 (average of 2 measures) or taking anti-hypertensive medication Method of assessing risk factor/exposure 1: Self-report: medication Direct measurement: BP Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Baseline cognitive status ApoeE polymorphism, Depressive symptomatology Methods(s) of assessing cognitive status: Other – >=4 point decline on MMSE between baseline and 4 year f/u Informant interview?: No | 1) Follow-up rate: 1,255/1373 completed 2 yr f/u 1172/1373 completed 4 year f/u Non participants had lower MMSE at baseline (27.1 vs. 28.2) 2) Important baseline differences: HTN associated with: male, heavy drinking, smoking and higher BMI; MMSE scores were similar 3) Outcome of interest #1 HTN: OR for cognitive decline = 2.8 (1.6 – 5.0) Sensitivity analysis using SBP ≥ 140 or DBP ≥ 90 to define HTN: OR for cognitive decline = 2.8 (1.1 to 2.9) 4) Outcome of interest #2 HTN and antihypertensives High BP with anti-HTN medication: OR=4.3 (2.1–8.8) High BP w/o anti-HTN medication: OR=1.9 (0.8 – 4.4) Normal BP with anti-HTN medication: OR=1.2 (0.6–2.2) 1 (reference) 5) Outcome of interest #3 Anti-HTN medication at baseline: OR for cognitive decline = 1.1 (0.7 –1.7) | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Partial, insufficient detail on selection criteria. 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Partial 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Unverzagt, Kasten, Johnson, et al., 2007 Advanced Cognitive training for Independent and Vital Elderly (ACTIVE) | Geographical location: Birmingham Al; Detroit Mich; Boston Mass; Baltimore Md; Indianapolis In; State College Pa; Setting: Other – Senior Housing Community Centers Hospitals Clinics Study design: RCT Test intervention: Reasoning Training Memory Training Speed Training. Comparator intervention(s): No Training (Control) Number of participants enrolled: 2832 Duration of follow up: 2 years Time from risk factor assessment to final cognitive assessment: 2 years | Age: Mean (SD): 73.6 (5.9) Sex: [n (%)] Female: 2078 (74.16%) Male: 754 (25.84%) Race/ethnicity: [n (%)] 26% Black Baseline cognitive status: MMSE ≥ 23 No self reported AD Inclusion criteria: NR Exclusion criteria: < 65 yrs of age; functional impairment ( ≥ 2ADLdisabilities); cognitive decline (MMSE score ≤ 22); self reported AD/stroke/uncertain cancer; severe losses in vision, hearing, or communicative ability that would interfere with study participation; recent cognitive training; or unavailable during the study period | Risk factor/exposure 1: NA Method of assessing risk factor/exposure 1: NA Covariates/potential confounders adjusted for in analyses: Cant tell. From the manuscript, it appears that they did not control for age, sex, or education. Method(s) of assessing cognitive status: MMSE and self report To divide the baseline sample into memory normal and memory impaired they used the AVLT test. Informant interview?: No | 1) Follow-up rate: 2832 randomized. 2244 analyzed at year 2. Follow up: 79% However, since they did ITT, 2802were included in the analysis. 2) Important baseline differences: The memory impaired group was older and had lower MMSE scores. 3) Outcome of interest #1 At years 1 and 2 the memory normal group (n=2580) who received- memory training did better than controls on memory tests. Year 1 :Effect size= 0.254, p<0.001 Year 2: Effect size= .214, p<0.001 reasoning training did better than controls on reasoning tests Year 1 Effect size= 0.416, p<0.001 Year 2 Effect size= 0.262, p<0.001 speed training did better on speed processing tests Year 1 effect size= −1.238, p<0.001 Year 2 effect size= −0.886, p<0.001 (negative effect sizes indicate better performance of this groups on the raw scores) 4) Outcome of interest #2 At years 1 and 2 the memory impaired group (n=193) who received- memory training did better no than controls on memory tests. reasoning training did better than controls on reasoning tests in year 2 only Year 1 Effect size= 0.208, p>0.05 Year 2 Effect size= 0.276, p<0.05 speed training did better on speed processing tests Year 1 effect size= −1.100, p<0.001 Year 2 effect size= −0.755, p<0.001 | Comments: None Quality assessment: For RCTs: 1) Baseline comparability? Can’t Tell 2) Valid AD/cognitive outcomes assessment? Can’t Tell 3) Subjects/providers blind? Partial 4) Outcome assessors blind? Yes 5) Incomplete data adequately addressed? Can’t Tell 6) Differential dropout rate < 10%? Yes 7) Overall dropout rate < 30%? Yes 8) Conflict of interest reported and insignificant? No 9) Randomization adequate? Yes 10) Allocation concealment adequate? Can’t Tell
van Gelder, Tijhuis, Kalmijn, et al., 2006 Finland, Italy, the Netherland s Elderly (FINE) Study | Geographical location: Finland, Italy, the Netherlands Setting: Community Study design: Prospective cohort Number of participants enrolled: 1383 Duration of follow up: 15 years Time from risk factor assessment to final cognitive assessment: 10 years. | Age: Range: 65 – 84 years Sex: Female: 0% Male: 100% Race/ethnicity: [n (%)] NR Baseline cognitive status: MMSE >24 Inclusion criteria: Finnish, Dutch, or Italian survivor of the Seven Countries Study Male Exclusion criteria: Female Institutionalized MMSE score ≤ 18 | Risk factor/exposure 1: Marital Status Method of assessing risk factor/exposure 1: Self-report Risk factor/exposure 2: Living situation Method of assessing risk factor/exposure 2: Self-report Covariates/potential confounders adjusted for in analyses: Age Country Educational level Smoking status Alcohol Consumption Baseline cognitive status Prevalence of MI Stroke Diabetes Cancer Hypertension Physical activity Depression Functional status For the analysis of marital status, living situation was included as a covariate. Method(s) of assessing cognitive status: Other – MMSE Informant interview?: No | 1) Follow-up rate: 1363 men were recruited in 1985. Information for 1042 men in 1990. Follow up for year 2000 NR. 2) Important baseline differences: who were not included in the present study were older (in 1990, mean ageof 79 years vs 76 years, p < .001), had lower education (5 years vs 7 years, p < .001), and were more likely to have a history of stroke (13% vs 5%, p < .001) compared to the men who participated. 3) Outcome of interest #1 After adjustment for age, education, country, smoking, alcohol consumption, prevalence of myocardial infarction, stroke, diabetes and cancer, living situation, and baseline cognitive functioning, men who were married from 1985–90 had a cognitive decline of 1.1 point (95% CI 0.9–1.4) over the 10 year follow up. Men who were married in 1985 but unmarried in 1990 had a cognitive decline of additional decline of 1.0 point(95% CI 0.1–1.9) Men who were unmarried in 1985 and 1990 had an additional decline of 1.3 points (95% CI 0.5–2.1) 4) Outcome of interest #2 After adjustment of after adjustment for age, education, country, smoking, alcohol consumption, prevalence of myocardial infarction, stroke, diabetes and cancer, marital status, and baseline cognition men who lived with others in 1985 and 90 had a cognitive decline of 1.1 points (95% CI 0.8–1.4) Men who lived with others in 1985 but alone in 1990 had an additional decline of 1.1 points (95% CI¼0.2– 2.0) Men who lived alone in 1985 and 1990 had an additional cognitive decline of 2.7 points (95% CI 1.7–3.7) | Comments: We do not know the rate of follow up. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? No 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Can’t Tell 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Verghese, LeValley, Derby, et al., 2006 Bronx Aging Study | Geographical location: NY, NY Setting: Community Study design: Prospective cohort Number of participants enrolled: 488; 437 in relevant subsample Duration of follow up: 2713 person-years. Mean: 5.6 yrs ± 4.1. 21-year study period. Time from risk factor assessment to final cognitive assessment: Mean: 5.6 yrs ± 4.1. 21-year study period. | Age: [underlined: No aMCI:] 79.0 ± 3.1 [underlined: Incident aMCI:] 78.9 ± 2.8 Sex: Female: [underlined: No aMCI:] 64.7% [underlined: Incident aMCI:] 58.6% Male: [underlined: No aMCI:] 35.3% [underlined: Incident aMCI:] 41.4% Race/ethnicity: White: [underlined: No aMCI:] 89.2% [underlined: Incident aMCI:] 89.3% Baseline cognitive status: Non-demented Inclusion criteria: English speaking, age between 75 and 85 yrs, community dwelling and <= 8 errors on Blessed Information Memory Concentration Test. Exclusion criteria: Prevalent aMCI. Severe visual or hearing impairment, Parkinson’s disease, liver disease, alcoholism, or known terminal illness. | Risk factor/exposure 1: Leisure activities Method of assessing risk factor/exposure 1: Self-report 6 cognitive activities and 10 physical activities Cognitive-activity and physical-activity scales in units of activity-days per week (range: 0–42 for cognitive activity and 0–70 for physical activity). Scale scores not dichotomized. Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Chronic illnesses (Participation in other leisure activities when analyzing individual leisure activities). Method(s) of assessing cognitive status: “Subjects with suspected dementia received further w/u. Triggers for w/u included: new symptoms, staff observations, Blessed test score change of 4 points or more than 8 errors, or worsening neuropsych test scores. NINCDS-ADRDA DSM-IIIR “The concept of aMCI evolved after study was launched; we adapted current aMCI criteria to diagnose cases.” Criteria for aMCI: 1) no dementia 2) memory impairment: >= 3 errors on 5-item Blessed test memory phrase 3) memory symptoms 4) normal cognitive function (verbal IQ >84 and score of less than 8 on the Blessed test) 5) generally preserved activities of daily living Informant interview?: Yes, when available | 1) Follow-up rate: 437 of 488 enrolled (89.5%) in Bronx Aging Study. 2) Important baseline differences: NA 3) Outcome of interest #1 58 incident cases of aMCI; 84 incident cases of dementia (43 AD, 15 mixed AD) 26 incident cases of dementia after meeting aMCI criteria (11 AD, 8 mixed AD and vascular dementia, 4 vascular, and 3 other) The 58 incident aMCI patients had lower baseline cognitive ability but not physical activity scale scores. None of the individual cognitive and physical leisure activities showed independent associations wit lower risk of aMCI in the fully adjusted models. 4) Outcome of interest #2 A 1-point increment in cognitive activity score was associated with a reduced risk of aMCI (HR, 0.949; 95% CI, 0.910–0.990), but a 1-pt increment in physical activity score was not (HR=0.970, 95% CI 0.933 to 1.008). A 1-point increment in cognitive activity score was associated with a reduced risk of aMCI or Dementia (HR, 0.946; 95% CI, 0.921–0.972), but a 1-pt increment in physical activity score was not associated (HR=0.985, 95% CI 0.967 to 1.008). | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Partial 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No. 4) Adequate description of the cohort?: Yes 5) Validated method for ascertaining exposure?: No (leisure activity) 6) Validated method for ascertaining clinical outcomes?: Partially, aMCI criteria applied retrospectively 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Partial 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes
Verghese, Lipton, Katz, et al., 2003 Bronx Aging Study | Geographical location: NY, NY Setting: Community Study design: Prospective cohort Number of participants enrolled: 469 Duration of follow up: 2702 person-years. Median f/u of 5.1 yrs. Mean f/u for subjects in whom dementia did not develop: 5.6 ± 4.1. Mean f/u for subjects in whom dementia did develop: 5.9 ± 4.1. Time from risk factor assessment to final cognitive assessment: Median 5.1 yrs | Age: [underlined: No dementia:] 78.9 ± 3.1 [underlined: Dementia:] 79.7 ± 3.1 Sex: Female: [underlined: No dementia:] 63% [underlined: Dementia:] 67% Male: [underlined: No dementia:] 37% [underlined: Dementia:] 33% Race/ethnicity: White: [underlined: No dementia:] 92% [underlined: Dementia:] 91% Other: [underlined: No dementia:] 8% [underlined: Dementia:] 9% Baseline cognitive status: Non-demented Inclusion criteria: English speaking, age between 75 and 85 yrs community dwelling. Exclusion criteria: Severe visual or hearing impairment, Parkinson’s disease, liver disease, alcoholism, or known terminal illness. | Risk factor/exposure 1: Frequency of leisure activities. Method of assessing risk factor/exposure 1: Self-report Cognitive-activity and physical-activity scales in units of activity-days per week. Scales dichotomized to “rare participation” vs. “frequent participation”. 6 cognitive activities and 11 physical activities Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Medical illness Baseline Blessed test score Participation in other leisure activities. Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Informant interview?: No | 1) Follow-up rate: 469 of 488 enrolled (96.1%). 2) Important baseline differences: NA 3) Outcome of interest #1 Incident dementia in 124 (61 with AD) 4) Outcome of interest #2 Reading, playing board games, playing musical instruments, and dancing were associated with reduced risk of dementia. A 1-point increment in cognitive activity score was associated with a reduced risk of dementia (HR, 0.93; 95% CI, 0.90–0.97), but a 1-pt increment in physical activity score was not (HR=1.00). Results were similar for AD and vascular dementia. HR reported for all activities in Table 2 in article. | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Partial 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? No 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Partial 9) Completeness of follow-up? Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate? Yes
Virtanen, Singh- Manoux, Ferrie, et al., 2009 Whitehall II study | Geographical location: London, England Setting: Community Study design: Prospective cohort Number of participants enrolled: 2214 Duration of follow up: 5 years Time from risk factor assessment to final cognitive assessment: 5 years | Age: Mean (SD): 52.1 Sex: [n (%)] Female: 23% Male: 77% Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Office staff from 20 London-based Civil Servant depts. Aged 35–55 between 1985 and 1988. Exclusion criteria: None | Risk factor/exposure 1: “How many hours do you work per week in your main job including work brought home?” “How many ours do you work in an average week in your additional employment?” Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Marital status Follow-up employment status Occupational grade Income Physical health indicators Psychological stress Anxiety Sleep problems Health risk behaviors Social support Family stress Job strain Method(s) of assessing cognitive status: Other – Decline from baseline to follow-up on tests of memory, reasoning, vocabulary, phonemic verbal fluency, and semantic verbal fluency Informant interview?: No | 1) Follow-up rate: 2214/3597 2) Important baseline differences: Differed by # hours worked on: sex, marital status, educational level, income, and psychological distress 3) Outcome of interest #1 Compared to those who worked ≤ 40 hrs/wk, those who worked: 41–55 hrs/wk declined more on reasoning test (mean difference (−2.23; SE = 0.37; p = 0.046) >55 hrs/wk declined more on reasoning test (mean difference −2.9; SE=0.49; p = 0.007) Test for linear trend, p = 0.036 | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Partial 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes, but because young cohort – not much decline 9) Completeness of follow-up? Partial 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Waldstein, Giggey, Thayer, et al., 2005 Baltimore Longitudinal Study of Aging (BLSA) | Geographical location: USA, majority from Baltimore, MD – Washington, D.C. area Setting: Community Study design: Prospective cohort Number of participants enrolled: 847 Duration of follow up: visits every 2.32 (0.8) yrs, mean 2.7 (1.5) visits Time from risk factor assessment to final cognitive assessment: Calculated average 6.26 years (mean number of visits multiplied by mean number of years between visits) | Age: Mean (SD): 70.6 (8.5) Sex: Female: 344 (41%) Male: 503 (59%) Race/ethnicity: White 84.2% Non-white 15.8% Baseline cognitive status: Non-demented Inclusion criteria: Participating in the BLSA Exclusion criteria: Dementia Cerebrovascular disease, including stroke Renal failure | Risk factor/exposure 1: Hypertension Method of assessing risk factor/exposure 1: Direct measurement once in each arm at least 90 min post breakfast, averaged Covariates/potential confounders adjusted for in analyses: Age, education, alcohol smoking antihypertensives depression Method(s) of assessing cognitive status: change in test score Informant interview? No | 1) Follow-up rate: Not reported in detail. Participants had different number of follow-up assessments 2) Important baseline differences: NR 3) Outcome of interest #1 Only significant result was a 3-way interaction of baseline age, time interval, and quadratic systolic BP for the BVRT and the Boston Naming Test. For the BVRT, among younger individuals (age 60 at baseline), those with higher systolic BP made more errors on the BVRT than those with normal BP but improved over time (ie, practice effects). In contrast, among older individuals (age 80 at baseline), those with higher systolic BP declined in BVRT performance over time. On the Boston Naming Test, younger individuals (age 60 at baseline) with higher systolic BP performed more poorly than those with lower systolic BP across testing sessions. For older individuals (age 80 at baseline), those with higher systolic BP declined in performance over time. | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Partial 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Can’t Tell 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Wang, Wahlin, Basun, et al., 2001 Kungsholmen study subset | Geographical location: Stockholm Sweden Setting: Community Study design: Prospective cohort Number of participants enrolled: 668 selected from initial sample. 443 included as non demented. Duration of follow up: 3 years. Time from risk factor assessment to final cognitive assessment: 3 years | Age: Range: 75–101 Sex: [n (%)] Female: 298 (80.54%) Male: 72 (19.46%) Race/ethnicity: [n (%)]NR Baseline cognitive status: Normal Non-demented Inclusion criteria: Born in 1912, Living in Kungsholmen area. Exclusion criteria: Refusing blood test. On folate or B12 replacement therapy. | Risk factor/exposure 1: B12 Method of assessing risk factor/exposure 1: Direct measurement Blood test with cut off of B12≤ 150 pmol/L being low. 2^nd^ cut off: B12≤ 250 pmol/L being low Risk factor/exposure 2: Folate Method of assessing risk factor/exposure 2: Direct measurement Blood test with cut off of ≤ 10 nmol/L being low. 2^nd^ cut off: ≤ 12 nmol/L being low. Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Baseline cognitive status Method(s) of assessing cognitive status: DSM III R Informant interview?: Yes | 1) Follow-up rate: 86 out of the 370 subjects died before the follow up period. Information on them was derived from hospital records. 2) Important baseline differences: Patient with low B12 scores were less educated at baseline. Patient with low Folate scores were lower MMSE scores at baseline. 3) Outcome of interest #1 RR risk of incident AD during the three year follow up after adjusting for ages, sex and education: B12 ≤ 150 VS ≥150 pmol/L = 1.6, 95% CI 0.9, 2.8 Folate ≤ 10 VS ≥10 nmol/L= 1.7 95% CI 1.0, 3.4 Both B12 and Folate: 2.1; 95% CI 1.4, 3.8 4) Outcome of interest #2 When low levels were defined as B12 ≤250 pmol/L and folate ≤ 12 nmol/L, the adjusted RR for AD was 7.0 (95% CI 5 1.6 to 31.6) in subjects with MMSE score > 26 and was 1.4 (95% CI 5 0.7 to 2.7) in subjects with MMSE score ≤26 Low levels of vitamin B12 or folate after controlling for age, sex, education and baseline cognitive functioning: 1.4 (0.8–2.4) 5) Outcome of interest #3 No interaction between B12 and folate. | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Partial. Not sure if either b12 or folate approach is entirely valid.
Wengreen, Munger, Corcoran, et al., 2007 Cache County Study | Geographical location: Cache County, UT Setting: Community Study design: Prospective cohort Number of participants enrolled: 3832 Duration of follow up: average 7.2 yrs Time from risk factor assessment to final cognitive assessment: average 7.2 yrs | Age: Mean (SD): Male 74.2 (6.5) Female 75.0 (6.8) Sex: [n (%)] Female: 2066 (53.9%) Male: 1566 (46.1%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: ≥ 65 yo, residents of Cache County Exclusion criteria: NR | Risk factor/exposure 1: Intake of antioxidants (vitamins C & E and carotenes) Method of assessing risk factor/exposure 1: Self-report Dietary food frequency questionnaire Covariates/potential confounders adjusted for in analyses: Several different models with different adjustments Method(s) of assessing cognitive status: Modified MMSE (3MS). Conducted in person at baseline and at f/u visits 2 and 3. Informant interview?: No | 1) Follow-up rate: 3632/3832 (94.8%) 2) Important baseline differences: Higher baseline 3MS scores in individuals with increasing quartiles of Vitamin C intake alone and combined with Vitamin E 3) Outcome of interest #1 Lower levels of intake of vitamin C, E and carotene had greater acceleration of the rate of 3MS decline over time compared to those with higher levels of intake. Conclusion: “High antioxidant intake from food and supplement sources of vitamin C, vitamin E, and carotene may delay cognitive decline in the elderly.” 4) Outcome of interest #2 See Table 3 for differences in mean baseline MS3 score across increasing quartile of intake of vitamins. p-trend reported across quartiles of intake. No single measure of association reported. | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Wetherell, Reynolds, Gatz, et al., 2002 Swedish Adoption/Twin Study of Aging | Geographical location: Sweden Setting: Community Study design: Prospective cohort Number of participants enrolled: 704 Duration of follow up: Up to 9 years Time from risk factor assessment to final cognitive assessment: NR | Age: Mean (SD): 63.7 (8.6) Sex: [n (%)] Female: 416 (59.0%) Male: 288 (41.0%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Same sex twins born between 1886 and 1958 reared apart & control group reared together matched on gender, age, county of birth Age >=50 during study Exclusion criteria: Dementia at anypoint in f/u | Risk factor/exposure 1: Anxiety/neuroticism Method of assessing risk factor/exposure 1: Self-report – 9-item short-form of the Eyesenck Personality Inventory Neuroticism Scale Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Method(s) of assessing cognitive status: Other – 11 cognitive measures: Wechsler Adult Intelligence Scale Infomration subtest; Synonymes; Analogies; Figure Logic; Koh’s Block Design; Card Rotations; Figure Identifiiation; Symbol Digit; Digit Span, Names and Faces Pairs; Thurstone’s Picture Memory Informant interview?: No | 1) Follow-up rate: 75.5% 2) Important baseline differences: NR 3) Outcome of interest #1 No significant association between neuroticism and cognitive change for any of the measures | Comments: Random effects model for analysis Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? No, neuroticism is a proxy for anxiety and not a clinical disorder. 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Partial, not given for exposed/unexposed. 10) Analysis controls for confounding? Partial, does not control for other psychiatric conditions. 11) Analytic methods appropriate? Yes
Williamson, Espeland, Kritchevsky, et al., 2009 | Geographical location: Winston Salem, NC and Palo Alto, CA USA Setting: Community Study design: RCT Test intervention: Physical activity: combination of aerobic, strength, balance and flexibility over a period of 12 mos Comparator intervention(s): Successful aging health education Number of participants enrolled: 102 Duration of follow up: 1 year Time from risk factor assessment to final cognitive assessment: Not applicable | Age: Mean (SD): 77.4 (4.3) Sex: [n (%)] Female: 72 (70.6) Male: 30 (29.4) Race/ethnicity: [n (%)] Caucasian: 83 (81.4) African Am: 14 (13.7) Hispanic: 2 (2.0) Other/mixed: 2 (2.0) Baseline cognitive status: Non-demented Inclusion criteria: Age 70–89 years. Sedentary life style (<20 min/wk in structured physical exercise), able to walk 400 m within 15 minutes without sitting and without using any assistive device, Short Physical Performance Battery Exclusion criteria: NR | Risk factor/exposure 1: Physical exercise Method of assessing risk factor/exposure 1: Self-report Direct measurement Covariates/potential confounders adjusted for in analyses: Baseline cognitive status Clinical site Method(s) of assessing cognitive status: Other – longitudinal change on cognitive tests (DSST, RAVLT, 3MS, modified Stroop) from baseline to 12 mos Informant interview?: No | 1) Follow-up rate: 93/102 had cognitive testing at final time point 2) Important baseline differences: No differences on a number of demographic, medical, and function variables 3) Outcome of interest #1 Intervention group showed slight improvement on DSST at 12 mos, but difference not significant. Change on the other measures favored the non-intervention group, but differences were not significant. 4) Outcome of interest #2 Outcome that is indirectly related to outcomes of interest: Improvement in DSST was associated with improvement in total Short Physical Performance Battery, chair stand score, and balance score. | Comments: Question 2 Quality assessment: For RCTs: 1) Baseline comparability? Yes 2) Valid AD/cognitive outcomes assessment? Yes 3) Subjects/providers blind? No 4) Outcome assessors blind? Yes 5) Incomplete data adequately addressed?: Yes 6) Differential dropout rate < 10%? Yes 7) Overall dropout rate < 30%? Yes 8) Conflict of interest reported and insignificant? Can’t Tell 9) Randomization adequate? Yes 10) Allocation concealment adequate? Can’t Tell
Willis, Tennstedt, Marsiske, et al., 2006 Advanced Cognitive training for Independent and Vital Elderly. (ACTIVE) | Geographical location: Birmingham Al; Detroit Mich; Boston Mass; Baltimore Md; Indianapolis In; State College Pa; Setting: Other – [specify] Senior Housing Community Centers Hospitals Clinics Study design: RCT Test intervention: Reasoning Training Memory Training Speed Training. Comparator intervention(s): No Training (Control) Number of participants enrolled: 2832 Duration of follow up: 5 years Time from risk factor assessment to final cognitive assessment: 5 years | Age: Mean (SD): 73.6 Sex: [n (%)] Female: 2078 (74.16%) Male: 754 (25.84%) Race/ethnicity: [n (%)] 26% Black Baseline cognitive status: MMSE ≥ 23 No self reported AD Inclusion criteria: NR Exclusion criteria: < 65 yrs of age; functional impairment (≥2ADLdisabilities) cognitive decline (MMSE score ≥22); self reported AD; medical conditions associated with imminent functional decline or death; severe losses in vision, hearing, or communicative ability that would interfere with study participation; recent cognitive training; unavailable during the study period | Risk factor/exposure 1: Not Applicable – measuring training versus no training Covariates/potential confounders adjusted for in analyses: Age Baseline cognitive status for those who did booster training since they were younger and had higher mmse scores For non booster analysis independent variables were: ‘Fixed effects for treatment group, time, assignment to booster training, field site. time x training, booster x training’ Method(s) of assessing cognitive status: MMSE Other – Self Reported AD Informant interview?: No | 1) Follow-up rate: 2832 enrolled 2802 analyzed (ITT) Total attrition at 5 years – 1077 1755/2832= 62% 245 died; 595 withdrew; 214 were excluded by administrative decision and 23 were withdrawn by the family. 2) Important baseline differences: participants who were randomized to booster training were younger (P=.007) and had higher baseline MMSE scores (P=.008) compared with participants who were eligible and not assigned to booster training 3) Outcome of interest #1 Effect of Training on Cognitive Outcomes From Baseline to Year 5 presented as Mean change from baseline to year 5; Effect size (99% CI) Memory Training (outcome Memory) = −1.0 ; 0.23 (0.11 to 0.35) Reasoning Training (outcome reasoning)= 8.1 ; 0.26 (0.17 to 0.35) Speed Training (outcome processing speed) = 241.8; 0.76 (0.62 to 0.90) Speed Training (outcome reasoning) = 119.6; 0.15 (0.01 to 0.29) 4) Outcome of interest #2 Effect of Booster Training on Cognitive Outcomes From Baseline to Year 5 after controlling for baseline age and MMSE score presented as Effect size (99% CI) Reasoning Training (outcome reasoning)= 0.28 (0.12 to 0.43) Speed Training (outcome processing speed) = 0.85 (0.61 to 1.09) 5) Outcome of interest #3 None of the effect sizes for effect of training on functional outcomes from baseline to Year 5 reached statistical significance at the 99% confidence interval. | Comments: Good quality RCT. There may be some differences between the participants of this study and a community population. For RCTs: 1) Baseline comparability? Yes 2) Valid AD/cognitive outcomes assessment? Partial. The speed of processing task was invented by an ACTIVE investigator (or at least she owns part of the company). It is not clear that it is a validated test for this purpose. 3) Subjects/providers blind? Partial 4) Outcome assessors blind? Yes 5) Incomplete data adequately addressed? Yes 6) Differential dropout rate < 10%? No 7) Overall dropout rate < 30%? No 8) Conflict of interest reported and insignificant? Partial 9) Randomization adequate? Yes 10) Allocation concealment adequate? Can’t Tell
Wilson, Bennet, Bienias, et al., 2003 Chicago Health Aging Project. | Geographical location: Chicago, USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 6158 enrolled. 1175 dies before first follow up. Of 4983 alive, 4392 completed first follow up (88.1%). This was considered to be the study sample. Duration of follow up: 5.3 years Time from risk factor assessment to final cognitive assessment: 6 years. Interviews done over 3 yr intervals. Average of 2.6 interviews per person. | Age: Mean (SD): 73.9 (6.5) Sex: [n (%)] Female: 2727 (62%) Male: 1665 (38%) Race/ethnicity: [n (%)] AA: 2710 (61.7%) Other: 1682 (38.3%) Baseline cognitive status: All (none excluded based on cognitive status) Inclusion criteria: Residents of the Chicago area. ≥ 65 yrs of age. Exclusion criteria: NR | Risk factor/exposure 1: Cognitive activity. Method of assessing risk factor/exposure 1: Self-report of number of activities on a 5 point scale-then converted into a composite score. Risk factor/exposure 2: Depression Method of assessing risk factor/exposure 2: Self-report CESD Covariates/potential confounders adjusted for in analyses: [delete any from the list below that do not apply and add items as needed] Age Race Sex Educational level Method(s) of assessing cognitive status: Other – [specify] Cognitive change on global index of cognitive function. Informant interview?: No | 1) Follow-up rate: Can’t tell. It appears that 88.1% of those alive at the first follow up completed at least one follow up interview and were included in the analysis. However, the number of participants who completed the second follow up is unknown. 2) Important baseline differences: Can’t tell. 3) Outcome of interest #1 The rate of cognitive decline was 0.064 units per year on the global measure of cognition Frequency of cognitive activity was associated with rate of cognitive decline. For each point on the cognitive activity scale, cognition decreased by 0.012 units, or about 19%. SE= 0.003, P <0.001 Compared to a person with infrequent cognitive activity (score = 2.14, 10th percentile), rate of global cognitive decline was reduced by about 35% in a person with frequent cognitive activity (score = 4.00, 90th percentile) 4) Outcome of interest #2 After controlling for disability, number of medical conditions, CES-D score, age, sex, race, and education, cognitive activity continued to be related to reduced cognitive decline (estimate = 0.010, SE = 0.004, p =0.003). | Comments: Since participants of all cognitive levels were included, this could introduce some differences in prognosis within the sample. . Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Partial, 79% of the community responded to the invitation to participate. But all cognitive levels included. 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Can’t Tell 10) Analysis controls for confounding? Partial. Not controlled for baseline cognitive function. 11) Analytic methods appropriate? Yes
Wilson, Bienias, Berry-Kravis, et al., 2002 Religious Orders Study | Geographical location: 40 sites across the USA Setting: Community - Religious orders Study design: Prospective cohort Number of participants enrolled: 669 Duration of follow up: 2–8 years Annual assessment Average 5.9 to 6 Time from risk factor assessment to final cognitive assessment: Up to 8 years | Age: Means(sd) e2: 75.7 (7.3) yrs e3: 75.7 (6.7) yrs e4 74.8 (6.3) yrs Sex: [n (%)] Female: 435 (65%) Male: 234 (35%) Race/ethnicity: [n (%)] 622 (93%) white non-hispanic Baseline cognitive status Non-demented Inclusion criteria: Religious orders member at 1 of 40 groups. Age at least 65. Not demented Exclusion criteria: Dementia. | Risk factor/exposure 1: Apolipoprotein E ɛ4 APOE ɛ4 Method of assessing risk factor/exposure 1: Direct measurement Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Time since baseline Method(s) of assessing cognitive status: 19 tests 7 assessed episodic memory (world list memory, recall, and recognition; immediate and delayed recall logical memory and East Boston); Semantic memory (verbal fluency); Boston naming; National adult reading test; extended range vocabulary; Working memory (digits forward, digits backward, digit ordering and alpha span); Perceptual speed (symbol digit modalities test and number comparison); visuospatial ability (judgment of line orientation, standard progressive matrices). Other – rate change cognitive test Informant interview?: No | 1) Follow-up rate: 98% 2) Important baseline differences: NR 3) Outcome of interest #1 Random effects model Rate of episodic memory change ɛ2/2 or 2/3: +.016 ɛ3/3: −.022 ɛ4/4 or 3/4: −.073 ɛ2 vs ɛ3/3 p<.05 ɛ4 vs ɛ3 p<.001 No difference between ɛ2 and ɛ3 in other cognitive domains ɛ4 declined more rapidly than ɛ3/3 in semantic memory and perceptual speed, but not in working memory or visuospatial ability ɛ2 semantic memory decline is slower than ɛ3/3, but there is no effect in other cognitive domains. | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? 2) Partial. Required participants agree to autopsy. 3) Selection minimizes baseline differences in prognostic factors? Yes 4) Sample size calculated/5% difference? No 5) Adequate description of the cohort? Yes 6) Validated method for ascertaining exposure? Yes 7) Validated method for ascertaining clinical outcomes? Partial 8) Outcome assessment blind to exposure? Yes 9) Adequate follow-up period? Yes 10) Completeness of follow-up? Yes 11) Analysis controls for confounding? Yes 12) Analytic methods appropriate? Yes
Wilson, Hebert, Scherr, et al., 2009 Chicago Health and Aging Project | Geographical location: Southside Chicago USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 6533 Duration of follow up: 6.5 (SD = 3.6) years Time from risk factor assessment to final cognitive assessment: 6.5 (SD = 3.6) years | Age: Mean (SD): 72.2 years (SD = 6.1) Sex: [n (%)] Female: 61% Male: 39% Race/ethnicity: [n (%)] 67% were African American Baseline cognitive status: All Inclusion criteria: Older residents of the Chicago Southside area. Completed at least one follow up interview. Exclusion criteria: NR | Risk factor/exposure 1: Educational attainment Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Sex Five chronic medical conditions was obtained from self report of heart attack or myocardial infarction, hypertension, stroke, diabetes mellitus, and cancer Method(s) of assessing cognitive status: Other – longitudinal change on the immediate and delayed recall of the East Boston Story Oral form of the Symbol Digit Modalities Test Mini-Mental State Examination Informant interview?: No | 1) Follow-up rate: 10,068 people interviewed at baseline 1,552 died before the first follow-up interview and 1,580 had not yet reached the date scheduled for the first follow-up. Among the 6,936 eligible for follow-up, 6,533 (94%) completed at least one follow-up interview. 2) Important baseline differences: Higher education associated with younger age (p < 0.001) and white race (p < 0.001) 3) Outcome of interest #1 No linear association between education and rate of change in cognitive function. Models that allowed for non-linearity in education and its relation to cognitive decline showed that education was associated with change in cognitive performance over time (coefficient >−0.001; se: <0.001; p = 0.005). The rate of cognitive decline at average or high levels of education was slightly increased during earlier years of follow-up but slightly decreased in later years in comparison to low levels of education. Findings were similar among black and white participants. 4) Outcome of interest #2 Cognitive performance improved with repeated test administration, but there was no evidence that retest effects were related to education or attenuated education’s association with cognitive change (Education x retest 4: coefficient <−0.001; se: 0.039; p = 0.990) | Comments: Question 2 – no cat Dx Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Wilson, Krueger, Arnold, et al., 2007 Rush Memory & Aging Project | Geographical location: Chicago, IL Setting: Community Study design: Prospective cohort Number of participants enrolled: 857; 791 analyzed Duration of follow up: Mean 3.3 years. Range: 2–5 years. Time from risk factor assessment to final cognitive assessment: Mean 3.3 years. Range: 2–5 years. | Age: Mean (SD): 80.7 (7.1) Sex: [n (%)] Female: 600 (75.8%) Male: 192 (24.2%) Race/ethnicity: [n (%)] African-American 46 ((5.8%) Other 746 (94.2%) Baseline cognitive status: Non-demented Inclusion criteria: Participant in Rush Memory and Aging Project; agreement to annual in-home clinical evaluations; agreement of brain donation upon death; completed at least one follow-up evaluation Exclusion criteria: Dementia Dx @ baseline | Risk factor/exposure 1: Loneliness Method of assessing risk factor/exposure 1: Self-report – de Jong Gierveld Loneiness Scale (range 0–5)(Questionnaire) Risk factor/exposure 2: Social isolation (social network size [#] and participation in social activity (0–5 scale) Method of assessing risk factor/exposure 2: Self-report Covariates/potential confounders adjusted for in analyses: age, sex, and level of educational achievement and for social activity, social network, physical activity, cognitive activity, depressive symptoms, income, race/ethnicity, disability, and vascular risk factors Method(s) of assessing cognitive status: NINCDS-ADRDA Informant interview?: NO | 1) Follow-up rate: 92.3% 2) Important baseline differences: NR 3) Outcome of interest #1 After adjusting for age, sex, and level of educational achievement, risk of clinical AD (76 subjects) increased by approximately 51% for each point on the loneliness scale (relative risk [RR], 1.51; 95% [CI], 1.06–2.14) Social activity (0–5): RR 0.52 (95% CI 0.34 to 0.79) Social network size: RR 1.01 (95% CI 0.97 to 1.05) 4) Outcome of interest #2 Relation of loneliness to AD incidence after controlling for social network and social activity in the above model: RR, 1.45; 95% CI, 1.01–2.09 Additional analyses showed the association between loneliness and AD was unchanged after controlling for income, disability on the Katz scale and vascular risk factors and conditions. 5) Outcome of interest #3 Relation of Loneliness to Change in Cognitive Function after controlling for age, sex, and level of educational achievement in separate mixed effect models: Global cognition: Loneliness x time Estimated SE: −0.01 (0.01) P = .03 Episodic memory: Loneliness x time Estimate (SE) 0.00 (0.01) p = .79 Semantic memory: Loneliness x time Estimate (SE) − 0.02 (0.01) p = .01 Working memory: Loneliness x time Estimate (SE) − 0.02 (0.01) p = .09 Perceptual speed: Loneliness x time Estimate (SE) − 0.02 (0.01) p = .03 Visuospatial ability: Loneliness x time Estimate (SE) − 0.03 (0.01) p = .04 | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Partial 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Partial 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Wilson, Mendes De Leon, Barnes, et al., 2002 RELIGIOUS ORDERS STUDY | Geographical location: U.S. Setting: Community –Religious Orders Study design: Prospective cohort Number of participants enrolled: 879 screened; 801 eligible Duration of follow up: Mean 4.5 years Time from risk factor assessment to final cognitive assessment: Mean 4.5 years | Age: Range: Incident AD: 81.1(6.2) No AD: 74.3 (6.3) Sex: Incident AD (n=111) Female: 74 (66.7%) Male: 37 (33.3%) No AD (n=622) Female: 418 (67.2%) Male: 204 (32.8%) Race/ethnicity: Incident AD White, non-Hispanic = 105 (94.6%) No AD White, non-Hispanic =562 (90.4%) Baseline cognitive status: Non-demented Inclusion criteria: ≥ 65 years at baseline Consent to annual clinical evaluations Consent to brain donation at the time of death Exclusion criteria: Dementia at baseline | Risk factor/exposure 1: Cognitive activity frequency. Method of assessing risk factor/exposure 1: Self-report 7 common activities that involve information processing. Frequency rated on a 5-point scale: 5) 5 points: every day or about every day. 4) 4 points: several times a week. 3) 3 points: several times a month. 2) 2 points: several times a year. 1) once a year or less. Covariates/potential confounders adjusted for in analyses: Age Gender Education Cognitive activity score Method(s) of assessing cognitive status: 20 cognitive tests administered in a 45- minute session. MMSE for descriptive purposes. 7 tests of episodic memory; 4 tests of working memory; 2 tests of perceptual speed; and 2 tests of visuospatial ability Composite measures of global cognition. AD diagnosed according to NINCDS/ADRDA Informant interview?: No | 1) Follow-up rate: 724/801 (90%) 2) Important baseline differences: NA 3) Outcome of interest #1 Annual Rate of Change in Specific Cognitive Functions: Association with Cognitive Activity Frequency Estimate (SE), p value Working memory: 0.021 (0.008), p=.007 Perceptual speed: 0.026 (0.012), p=0.02 In random-effects models, a 1-point increase in cognitive activity was associated with reduced decline in global cognition (by 47%), working memory (by 60%), and perceptual speed (by 30%). 4) Outcome of interest #2 RR of Incident AD by Cognitive Activity Frequency Score: RR 0.67 (95% CI: 0.49, 0.92) A 1-point increase in cognitive activity score was associated with a 33% RR of AD (hazard ration, 0.67; 95% CI: 0.48, 0.92) 5) Outcome of interest #3 Results were comparable when terms for ApoE were added to the model. 6) Outcome of interest #4 Physical activity was not associated with risk of AD (HR, 1.00; 95% CI, 0.97–1.02). | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Partial. Required agreeing to autopsy as part of enrollment. 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Can’t Tell 6) Validated method for ascertaining clinical outcomes? Partial 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Wilson, Scherr, Hoganson, et al., 2005 Religious Order Study | Geographical location: Multiple US sites Setting: Community - members of Religious Orders Study design: Prospective cohort Number of participants enrolled: 859 Duration of follow up: Mean: 5.6 years Time from risk factor assessment to final cognitive assessment: Mean: 5.6 years | Age: Mean (SD): 75.0 (7.0) Sex: Female: 596 (69.4%) Male: 263 (30.6%) Race/ethnicity: African-American: 71 (8.3%) Other: 787 (91.7%) Baseline cognitive status: Non-demented Inclusion criteria: Catholic nuns, priests, and brothers from the Religious Orders Study Exclusion criteria: Dementia at baseline | Risk factor/exposure 1: Early life socioeconomic status (SES) indicators Method of assessing risk factor/exposure 1: Self-report SES: 1) parental education, 2) paternal occupation, 3) # of children in the family. Also, 3 other SES indicators based on county of birth: 4) literacy rate, 5) % of children in county in school, 6) Duncan SES. The 7^th^ SES indicator was participant’s own education level attained. Summary measures used for early life household and community SES level. Covariates/potential confounders adjusted for in analyses: Age Sex Educational level SES indicators Method(s) of assessing cognitive status: NINCDS-ADRDA Other: change in performance on cognitive tests over time Informant interview?: No | 1) Follow-up rate: 859/ 877 – 98% 2) Important baseline differences: NA 3) Outcome of interest #1 154 incident cases of AD. 4) Outcome of interest #2 Neither early life household (RR: 1.12, 95% CI: 0.88,1.42) nor community SES (RR: 1.35, 95% CI: 0.93, 1.96) was related to risk of AD. (RR is for a 1-unit increase in each SES indicator) No significantly different findings when quadratic terms for SES indicators added. 5) Outcome of interest #3 Higher SES was related to slightly greater decline on semantic memory task. There were no other significant associations between independent variables and cognitive change over time. | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Partial 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? No 6) Validated method for ascertaining clinical outcomes? Partial 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Wilson, Scherr, Schneider, et al., 2007 RUSH MEMORY AND AGING PROJECT | Geographical location: Chicago area, USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 931 with baseline evaluation; 829 eligible at one year follow-up Duration of follow up: Mean of 3.5 (sd = 1.2) annual follow up assessments. Range: 2 – 6 follow-ups Time from risk factor assessment to final cognitive assessment: Mean of 3.5 (sd = 1.2) annual follow up assessments. Range: 2 – 6 follow-ups | Age: Mean (SD): 80.4 (7.4) Sex: Female: 581 (75%) Male: 194 (25%) Race/ethnicity: White (non-Hispanic): 705 (91%) Other: 70 (9%) Baseline cognitive status: Non-demented Inclusion criteria: Participating in the Rush Memory and Aging Project Agree to annual clinical evaluation Agree to donate brain at death Exclusion criteria: Dementia at baseline | Risk factor/exposure 1: Cognitive activity participation Method of assessing risk factor/exposure 1: Self-report. Structured questionnaire at baseline. Frequency of participate on a 5-point scale, from 1 = once a year or less, to 5= every day or about every day. Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Method(s) of assessing cognitive status: NINCDS-ADRDA MCI classified as evidence of impairment in at least one cognitive domain in the absence of dementia. Other: change in performance on cognitive tests over time Informant interview?: No | 1) Follow-up rate: 775/829 (93.5%) with f/u data 2) Important baseline differences: NR by cognitive activity level 3) Outcome of interest #1 More frequent current cognitive activity was associated with reduced incidence of AD (RR _ 0.58; 95% CI: 0.44, 0.77). More frequent past cognitive activity was also associated with reduced risk of AD (RR _ 0.56; 95% CI: 0.36, 0.88) 4) Outcome of interest #2 more frequent cognitive activity was associated with reduced incidence of MCI (RR _ 0.71; 95% CI: 0.58, 0.87). 5) Outcome of interest #3 More frequent current cognitive activity associated with less decline on global cognitive measure Estimate = 0.025; se=0.010; p = 0.015 | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Partial 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? No 6) Validated method for ascertaining clinical outcomes? Partial 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Wilson, Schneider, Boyle, et al., 2007 Religious Orders Study & Rush Memory and Aging Project | Geographical location: Chicago, USA & other USA locations Setting: Community Study design: Prospective cohort Number of participants enrolled: 1256 Duration of follow up: RMAP = 3.9 and for the combined group = 6.2 mean annual evaluations Range 1 – 13 yrs Time from risk factor assessment to final cognitive assessment: RMAP = 3.9 and for the combined group = 6.2 mean annual evaluations Range 1 – 13 yrs | Age: Mean (SD): 76.8(7.7) Sex: [n (%)] Female: 888(70.7%) Male: 368 (29.3%) Race/ethnicity: [n (%)] 1143 (91%) White non- Hispanic Baseline cognitive status: Non-demented Inclusion criteria: Catholic nuns priests and brothers who agreed to brain donation at death (ROS study) or participant in RMAP At least 1 year f/u Valid score on NEO neuroticism scale Exclusion criteria: Dementia or MCI | Risk factor/exposure 1: Depression – 10-item CESD 2: Distress proneness – 6 items from the 12- item NEO Five Factor Inventory (score ranges 0–48) Method of assessing risk factor/exposure 1: Self-report at baseline Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Method(s) of assessing cognitive status: NINCDS-ADRDA for AD MCI – cognitive impairment w/o meeting criteria for dementia Informant interview?: No | 1) Follow-up rate: 95.2% 2) Important baseline differences: Can’t tell 3) Outcome of interest #1 Association with MCI CESD for each depressive symptom, RR=1.06 (95% CI 1.002 to 1.120) Distress proneness RR for each one point increase = 1.02 (95% CI 1.01 to 1.04) When controlling for CESD score the association between distress proneness and MCI was not substantially changed, RR 1.02, 1.01 to 1.04 When controlling for distress proneness score the association between CESD and MCI was not significant RR=1.02, 0.96 to 1.09 | Comments: Unclear CESD-10 scoring; unclear if association is for each one point increase or each symptom endorsed Quality assessment: For observational studies: 1) Unbiased selection of the cohort: Partial. Required agreeing to autopsy. 2) Selection minimizes baseline differences in prognostic factors: Yes 3) Sample size calculated/5% difference: No 4) Adequate description of the cohort: Yes 5) Validated method for ascertaining exposure: Partial 6) Validated method for ascertaining clinical outcomes: Partial 7) Outcome assessment blind to exposure: Can’t Tell 8) Adequate follow-up period: Yes 9) Completeness of follow-up: Yes 10) Analysis controls for confounding: Yes 11) Analytic methods appropriate: Yes
Winnock, Letenneur, Jacqmin- Gadda, et al., 2002 PAQUID | Geographical location: Gironde, France Setting: Community Study design: Prospective cohort Number of participants enrolled: 2792 in PAQUID. Of these, 626 initially eligible by volunteering for APOE testing. Duration of follow up: Mean NR. Range: 1–8 yrs. Time from risk factor assessment to final cognitive assessment: Mean NR. Range: 1–8 yrs. | Age at baseline: Mean (SEM): 73.7 (0.26) Range: 65–94 Sex: NR Race/ethnicity: NR Baseline cognitive status: Non-demented Inclusion criteria: ≥ 65 yrs, living in southern France. Participants of PAQUID study who volunteered to give a blood sample for APOE phenotyping at the 1sr year f/u interview. Exclusion criteria: Dementia at baseline and at 1 ^st^ year of f/u. | Risk factor/exposure 1: Education Method of assessing risk factor/exposure 1: Self-report Risk factor/exposure 2: APOE Method of assessing risk factor/exposure 2: Direct measurement Covariates/potential confounders adjusted for in analyses: Age Sex Education Time Age by time APOE Random effects linear regression model, which takes into account the lack of independence of a subject’s measurements across time. Method(s) of assessing cognitive status: Assessments at 1, 3, 5, 8, & 10 yrs after baseline visit. Cognitive performance evaluated at each visit with a comprehensive battery of tests. DSM-IIIR for dementia, followed by neurologist evaluation to confirm diagnosis of dementia. Main outcome: MMSE scores at multiple timepoints Informant interview?: No | 1) Follow-up rate: 2792 in PAQUID. 626 in this study because they volunteered for APOE testing. Two analyses: 1) Excluded dementia at baseline or 1^st^ yr f/u (n=26). Sample size: 600/626 = 96% 2) Excluded dementia at baseline, 1^st^ year or 3^rd^ year f/u (n=53). Sample size: 547/626 = 87% MMSE f/u rates: 1-yr: 574 (95.7%) 3-yr: 508 (84.7%) 5-yr: 457 (76.2%) 8-yr: 364 (60.7%) Four MMSE measurements available in 332 participants (55.3%) 2) Important baseline differences: NA 3) Outcome of interest #1--APOE APOE was significantly associated with lower cognitive performance at baseline. Course of cognitive performance during the f/u was the same for both APOE carriers and noncarriers. 4) Outcome of interest #2—APOE and education Lower education level was associated with lower cognitive performance at baseline, and the effect of an APOE allele on cognitive performance disappeared after adjustment for education. APOE carriers show decreased MMSE scores compared with non- carriers, but the effect of APOE on cognition disappears after adjustment for education. Non-demented elderly people maintain a stable cognitive performance regardless of the their APOE phenotype. 5) Outcome of interest #3 Conclusions: 1) Baseline cognition related to APOE phenotype 2) APOE effects disappeared after adjustment for education 3) No global cognitive decline observed over time among non- demented participants 4) Level of global cognitive performance remained stable throughout f/u and was independent of APOE phenotype. | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Wright, Elkind, Luo, et al., 2006 Northern Manhattan Study (NOMAS) | Geographical location: Northern Manhattan, NY, USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 1428 analytical sample Duration of follow up: Mean 2.2 yrs (range 0.5–4.4) Time from risk factor assessment to final cognitive assessment: Mean 2.2 yrs (range 0.5–4.4) | Age: Mean (SD): 71 yr (9) Sex: Female: 957 (67%) Male: 471 (33%) Race/ethnicity: [n (%)] NR Baseline cognitive status: NR Inclusion criteria: At least 40 yrs old, no history of stroke, resident of North Manhattan for at least 3 mos, have a phone Exclusion criteria: None except as covered by inclusion criteria. | Risk factor/exposure 1: Alcohol Method of assessing risk factor/exposure 1: Self-report- at cognitive baseline asked questions about alcohol intake during past six months; details of quantity of wine, beer, and liquor were collected Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Baseline cognitive status Interval between cognitive testing Health insurance status HDL-C level BMI History of hypertension Diabetes Cardiac disease Smoking Depression Physical activity Method(s) of assessing cognitive status: Other – longitudinal performance on the TICS-m Informant interview?: No | 1) Follow-up rate: NR (cannot tell how many of those not included in analyses actually dropped out vs were missing alcohol data) 2) Important baseline differences: Trend (p<0.0001) toward those drinking less or no alcohol being younger, more likely to be female, had less than 8 yrs education, less likely to have insurance, more likely to be Hispanic, more likely to have hypertension, more likely to have diabetes, more likely to smoke, more likely to have a higher BMI, more likely to be depressed, and more likely to be physically active. Individuals who drank 1 drink/month to <1/week or > 2/day had higher homocysteine levels than never drinkers. Individuals who drank 1/week or more had higher baseline TICS-m scores than nondrinkers. 3) Outcome of interest #1 Drinking less than one drink a week (P=0.09), between one drink weekly up to two drinks daily (P=0.001), and more than two drinks daily (P=0.003) were associated with less cognitive decline on the modified Telephone Interview for Cognitive Status (TICS- m) compared to never drinkers.. 4) Outcome of interest #2 This dose-response relationship was not modified by the presence of an APOE-4 allele in a subsample | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Partial 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Partial 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Xu, von Strauss, Qiu, et al., 2009 Kungsholmen | Geographical location: Kungsholmen district of Stockholm, Sweden. Setting: Community Study design: Prospective cohort Number of participants enrolled: 1248 Duration of follow up: 9 year; (mean per person=5.1 years; maximum=10.5 years) Time from risk factor assessment to final cognitive assessment: ~6 yr | Age: Mean (SD): nl 81.4 (4.9) borderline DM 82.2(5.2) DM 81.6 (5.2) Sex: [n (%)] Female: 74.7% Male: 25.3% Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: all registered inhabitants who were living in the Kungsholmen district of Stockholm, Sweden, and were aged ≥75 years on 1 October 1987 were initially invited to participate in the project. Exclusion criteria: dementia | Risk factor/exposure 1: Diabetes mellitus Method of assessing risk factor/exposure 1: Direct measurement Medical record Other – medication use Covariates/potential confounders adjusted for in analyses: Age, sex, education, baseline MMSE score, BMI, APOE genotype and vascular disorders (i.e. heart disease, stroke, antihypertensive drug use and BP) were considered as potential confounders. Method(s) of assessing cognitive status: DSMIII-R Informant interview?: No | 1) Follow-up rate: 1248/1475 = 84.6 2) Important baseline differences: MMSE score; presence of heart disease; diastolic BP; use of antihypertensive drugs differ in nondiabetic, borderline and DM groups 3) Outcome of interest #1 Fully adjusted model AD with stroke Non-diabetic HR 1 Borderline DM 1.93 (.59–6.28) Undiagnosed DM 3.75 (.48–4.55) AD without vasc comorbidities Non-diabetic 1 Borderline HR 2.85 (1.29–6.3) Undiagnosed DM 4.74 (1.08–18.46) 4) Outcome of interest #2 Normal 1 Borderline HR 1.87 (1.11–3.14) <7.8mmol OR 0.34 (0.05–2.43) 7.7–11mmol 1.26 (0.46–3.62) >11mmol 1.08 (0.4–2.95) Undiagnosed DM 3.29 (1.2–9.01) | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Yaffe, Barnes, Nevitt, et al., 2001 Study of Osteoporotic Fxs | Geographical location: Baltimore, Minneapolis, Monongahela Valley (near Pittsburgh), Portland Oregon Setting: Community Study design: Prospective cohort Number of participants enrolled: 5925 Duration of follow up: Mean 7.5 yrs range Time from risk factor assessment to final cognitive assessment: Mean 7.5 years. Follow-up at both 6 and 8 years after initial assessment | Age: Mean (SD): 70.8 ±4.7 Range: ≥65 Sex: [n (%)] Female: 100% Race/ethnicity: [n (%)] Black women excluded Baseline cognitive status: shortened mmse ≥ 23/26 Inclusion criteria: Participant in the Study of Osteoporotic Fractures. Exclusion criteria: Shortened mmse < 23/26, women unable to stand up unaided from chair or walk up stairs (self reported), black women, women with missing baseline cognitive score, women with baseline physical limitations, women with missing information on physical limitations, women who did not complete baseline physical activity assessments | Risk factor/exposure 1: Physical activity Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age, Educational level Health status, functional limitation, depression score, stroke, dm, htn, mi, smoking, estrogen use Method(s) of assessing cognitive status: change in shortened mmse score. Change of ≥ 3 points over period of follow up defined cognitive decline. Informant interview?: No | 1) Follow-up rate: There were 7701 women who had a high enough baseline cognitive score and who did not report physical limitations at baseline. Of these, 8% (596) died, 3% were lost (238), 12% (942) did not have follow up cognitive testing, leaving 5925/7701 or 77% 2) Important baseline differences: Physical activity divided into quartiles. Those in higher quartiles were younger, more educated, more likely to drink and take estrogen, less likely to smoke with a lower bmi, lower depression scores, fewer medical comorbidities and less functional limitation. 3) Outcome of interest #1 Using lowest quartile of blocks walked per week as reference: Second had OR 0.87 (0.72 – 1.05) third OR 0.63 (0.52–0.77) highest quartile had OR 0.66 (0.54 – 0.82) Using total kilocalories per week into quartiles with the lowest as the reference: again OR Second 0.90 (0.74–1.09) Third 0.78 (0.64–0.96) Highest 0.74 (0.60–0.90) 4) Outcome of interest #2 Results are presented comparing the second, third and highest quartiles to the lowest with results stratified by age (at 70), by presence or absence of medical comorbidities and by education (at 12 yrs). These results do not appear otherwise adjusted. 5) Outcome of interest #3 The percentage decline in the shortened mmse score was also treated as a continuous variable. The difference between women in the higher quartiles and those in the lower quartiles was significant (p<0.001) 6) Outcome of interest #4 cognitive decline (defined as a three or more point drop in screener score) was present in 17% of those in highest activity quartile, 18% next, 22% next and 24% of those in lowest quartile. It is noted that these women had important baseline differences as above, however (particularly age, vascular disease, smoking). Baseline cognitive scores were also reported difference with p=0.001 but difference was between 25.1 in lowed group and 25.2 in other quartiles. | Comments: Question 2, no dx I suspect this is a secondary analysis in this study. Quality assessment: For observational studies: 1) Unbiased selection of the cohort?: Yes 2) Selection minimizes baseline differences in prognostic factors?: Yes 3) Sample size calculated/5% difference?: No 4) Adequate description of the cohort?: Partial 5) Validated method for ascertaining exposure?: Yes 6) Validated method for ascertaining clinical outcomes?: Yes 7) Outcome assessment blind to exposure?: Can’t Tell 8) Adequate follow-up period?: Yes 9) Completeness of follow-up?: Yes 10) Analysis controls for confounding?: Yes 11) Analytic methods appropriate?: Yes.
Yaffe, Blackwell, Gore, et al., 1999 Study of Osteoporotic Fractures | Geographical location: Baltimore, MD; Minneapolis, Minn; Monongahela Valley, PA; Portland, OR Setting: Community Study design: Prospective cohort Number of participants enrolled: 7511 Duration of follow up: 4 years Time from risk factor assessment to final cognitive assessment: 4 years | Age: Mean (SD): 72.8 (4.7) to 74.0 (5.2) Sex: [n (%)] Female: 7511 (100%) Male: 0 (0%) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Age >=65 yo Community dwelling Exclusion criteria: Black race Prior clinical diagnosis of dementia | Risk factor/exposure 1: Depressive symptoms Method of assessing risk factor/exposure 1: Self-report at baseline using the Geriatric Depression Scale (GDS, range 0–15) Covariates/potential confounders adjusted for in analyses: Age Educational level Baseline cognition Health status Exercise Alcohol use Funcational status Clinic site Method(s) of assessing cognitive status: Modified MMSE decline by >=3 points (mMMSE range 0–26) Change in Trails B, Digit symbol and mMMSE Informant interview?: No | 1) Follow-up rate: 645 died; 5781/7511 had follow-up (76.9%) Women w/o f/u had lower baseline cognitive and depression scores 2) Important baseline differences: Women with more depressive symptoms were older, reported more functional impairment, were less educated, exercised less, were less likely to report good health status and less likely to be married 3) Outcome of interest #1 Incident AD >=3 point decline on mMMSE (n=653 cases): OR for >=6 on GDS=2.1 (1.4–3.1); OR for 3–5 on GDS=1.6 (1.2–2.1) compared to 0–2 on GDS 4) Outcome of interest #2 MMSE decline of >=3 points Subgroup analysis educational level showed: <=8 years: OR for MMSE decline = 0.84 (0.49 to 1.43) > 8 years: 1.83 (95% CI 0.93 to 3.6) 5) Outcome of interest #3 Change in cognition Women with more depressive symptoms had a greater decline in cognitive scores for the Trails B (F=3.64, p=0.03), Digit Symbol (F=3.41, p=0.03) and modified MMSE (F=8.44, p<0.001) A sensitivity analysis excluding women with a modified MMSE of < 20 at baseline or who reported a history of physician-diagnosed stroke, dementia, or Parkinson disease at the time of f/u “did not substantially affect the results.” - data not given | Comments: Logistic regression for >=3 point decline in MMSE Only women; blacks excluded Quality assessment: For observational studies: 1) Unbiased selection of the cohort: Yes 2) Selection minimizes baseline differences in prognostic factors: Yes 3) Sample size calculated/5% difference: No 4) Adequate description of the cohort: Yes 5) Validated method for ascertaining exposure: Partial; validated scale but symptoms only 6) Validated method for ascertaining clinical outcomes: Partial; uncertain clinical significance 7) Outcome assessment blind to exposure: Can’t Tell 8) Adequate follow-up period: Yes 9) Completeness of follow-up: Partial, Loss to f/u associated with cognition and depression 10) Analysis controls for confounding: Yes 11) Analytic methods appropriate: Yes
Yaffe, Cauley, Sands, et al., 1997 | Geographical location: Monongahela Valley near Pittsburgh, PA Setting: Clinical – Monongahela Valley Clinic of the multicenter Study of Osteoporotic Fractures Study design: Prospective cohort Number of participants enrolled: 1750 1248 with cognitive testing Duration of follow up: Average 6.4 years Time from risk factor assessment to final cognitive assessment: 6 years | Age: Mean (SD): 71 Sex: [n (%)] Female: 100% Male: 0% Race/ethnicity: [n (%)] 100% white except for 3 Asian and 1 other. Baseline cognitive status: Non-demented Inclusion criteria: Women were over the age of 65 and living in the community. They were recruited from 1985 voter registration lists in selected zip codes within approximately 40 km of the clinic. Exclusion criteria: Men and black women because of lower risk of osteoporotic fractures. Dementia, Parkinson’s disease or stroke. | Risk factor/exposure 1: APOE genotype Method of assessing risk factor/exposure 1: Direct measurement Covariates/potential confounders adjusted for in analyses: Age Educational level Baseline cognitive status Depression Presence of severe tremor Method(s) of assessing cognitive status: Other – Modified MMSE (max score 26 Trails B Digit Symbol Cognitive decline was defined on each or any test if a woman had the largest 10^th^ percentile reduction in performance from initial score to repeat testing. Informant interview?: No | 1) Follow-up rate: 1248/1750= 71.3% Follow-up cognitive testing in 1138 1138/1248 = 91.2% 2) Important baseline differences: none 3) Outcome of interest #1 Presence of an APOE4 was significantly associated with worsening on all cognitive tests at follow-up compared to no E4 group (modified MMSE P=.01; Digit Symbol P=.05; Trails B P=.003) 4) Outcome of interest #2 Incidence of cognitive decline was 1.6 times higher in the E4 group (P<.03) and ranged from 1.2 times higher for Trails B to 2.4 times higher for modified MMSE. Homozygotes declined almost twice as fast as heterozygotes on all tests except Trails B. 5) Outcome of interest #3 Reduction on the modified MMSE was 0% for no E4; 1.9% for 1 E4; and 3.7% for 2 E4s (P<.001) Reduction on Digit Symbol was 6.2% for no E4; 9% for 1 E4 and 17.5% for 2 E4s. (P=.04) Reduction on Trails B was 5.9% for no E4; 25% for 1 E4 and 10.9% on 2 E4s (P=.002) | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Yaffe, Fiocco, Lindquist, et al., 2009 Health ABC | Geographical location: Memphis, TN Pittsburgh, PA Setting: Community Study design: Prospective cohort Number of participants enrolled: 2509 Duration of follow up: 8 years Time from risk factor assessment to final cognitive assessment: 3, 5 and 7 years | Age: Mean (SD): Maintainers 73 (2.6) Minor decline 73.6 (2.9) Major decline 74.3 (2.6) Range: 70–79 @ baseline Sex: [n (%)] Female: 1334 (53.2%) Male: 1175 (46.8%) Race/ethnicity: [n (%)] White 1612 (64.3% ) Black 897 (35.7%) Baseline cognitive status: 3MS>80 Inclusion criteria: a random sample of white and all black Medicare-eligible elders, within designated zip code areas, were contacted. To be eligible, participants had to report no difficulty with activities of daily living, walking a quarter of a mile, or climbing 10 steps without resting. They also had to be free of life-threatening cancer diagnoses and have no plans to move out of the study area for at least 3 years. Exclusion criteria: Difficulty with activities of daily living, be unable to walk a quarter of a mile, or climb 10 steps without resting. Have life-threatening cancer diagnoses or have plans to move out of the study area for at least 3 years. | Risk factor/exposure 1: diabetes Method of assessing risk factor/exposure 1: Self-report Direct measurement Medical record Other – use of medication Risk factor/exposure 2: Hypertension Method of assessing risk factor/exposure 2: Self-report Direct measurement Medical record Other – use of medication Risk factor/exposure 3: Depression Method of assessing risk factor/exposure 3: Other- use of CES-D 20 item Risk factor/exposure 4: Physical activity Method of assessing risk factor/exposure 4: Self-report Risk factor/exposure 5: Smoking Method of assessing risk factor/exposure 5: Self-report Risk factor/exposure 6: works or volunteers Method of assessing risk factor/exposure 6: Self-report Covariates/potential confounders adjusted for in analyses: Age Race Educational level APOE genotype Method(s) of assessing cognitive status: 3MS The participant-specific slopes of 3MS scores were estimated by best linear unbiased predictions using a linear mixed model with random intercepts and slopes. Participants with predicted slopes of 0 or greater (indicating no change or improvement in cognitive scores over time) were classified as maintainers. Those with predicted slopes less than 0 (decline in cognitive score over time) but no more than one SD below the mean of the slopes were classified as minor decliners. Those with predicted slopes more than 1 SD below the mean were classified as major decliners. Informant interview?: No | 1) Follow-up rate: 2509/3075 2) Important baseline differences: ‘major decliners’ older, more black, less educated, lower reading level, lower perceived social support, more likely to live with someone, lower self rated health, fewer drinkers, fewer exercisers, more smokers, more depressed, heavier, more HTN, more DM, more MIs, more CVAs, more e4s, higher il-6, lower triglycerides, higher fasting glc 3) Outcome of interest #1 In the multivariate model, baseline variables significantly associated with being a Maintainer vs a minor decliner were: age OR = 0.65, (0.55–0.77 per 5 years), white race OR= 1.72, (1.30–2.28), high school education level or greater (OR= 2.75, 95% CI 1.78–4.26), ninth grade literacy level or greater (OR = 4.85, 95% CI 3.00–7.87), weekly moderate/vigorous exercise OR = 1.31, 95% CI 1.06–1.62), and not smoking (OR= 1.84, 95% CI 1.14–2.97). 4) Outcome of interest #2 Minor vs Major Decliner APOE4 OR 2.31 (1.75–3.05) Education ≥12 OR 0.52 (.37–.72) 9^th^ grade literacy or greater OR 0.7 (0.5–.98) Not statistically significant: Htn, DM, drinking 1 alcoholic beverage/day CESD<16, not a current smoker. 5) Outcomes of interest #3 There is a table of all factors adjusted for all others for maintainer vs minor decliner and for major vs minor decliner. For htn OR 1.03 (0.83–1.28) and 1.29(0.97–1.73) Educ (self report) ≥ high school 2.75 (1.78–4.26) 0.52 (0.37–0.73) works or volunteers (self rpt) 1.24 (0.99–1.54) 0.96 (0.73–1.25) has enough social support 0.94 (0.73–1.21) 0.69 (0.51–0.91) drinks >1 etoh daily 1.33 (0.91–1.93) 0.67(0.36–127) moderate to vigorous exercise (>once a week) 1.31 (1.06–1.62) 0.97 (0.73–1.28) not current smoker 1.84 (1.14–2.97) 1.15 (0.72–1.84) ces-d < 16 1.23 (0.68–2.22) 0.70 (0.38–1.29) dm (self rpt OR use of meds OR fasting glc > 126 OR 2 hour challenge glc > 200) 0.91 (0.64–1.30) 1.35 (0.92 – 2.00) | Comments: Over 8 years, 30% of the participants maintained cognitive function, 53% showed minor decline, and 16% had major cognitive decline. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? No 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Yaffe, Kanaya, Lindquist, et al., 2004 Health, Aging and Body Composition (ABC) study | Geographical location: Memphis, TN and Pittsburgh, PA Setting: Community Study design: Prospective cohort Number of participants enrolled: 2632 38.6% of participants with metabolic syndrome. 61.4% without metabolic syndrome. Duration of follow up: 5 years Time from risk factor assessment to final cognitive assessment: Metabolic syndrome assessed at baseline. Final assessment at 5 years | Age: Mean (SD): 73.6 (2.9) Sex: [n (%)] Female: 52 Male: 48 Race/ethnicity: [n (%)] 60% white 40% black Baseline cognitive status: Non-demented Inclusion criteria: Random sample of 70 – 79 year old, Medicare eligible whites and blacks living in designated zip codes. Had to be well-functioning (self report of no difficulty in walking ¼ mile or climbing 10 steps without resting.) Exclusion criteria: Any difficulty with ADLs, clinical dementia (DSM IV dx), inability to communicate with interviewer, intention of moving out of vicinity in next year, active rx for cancer in prior 3 years, participation in a trial involving a lifestyle intervention. Subjects missing data on metabolic, inflammatory markers, or cognitive testing. | Risk factor/exposure 1: Metabolic syndrome defined by National Cholesterol Education Program 3^rd^ Adult treatment panel guidelines (NCEP-ATPIII). At least 3 of the following: 1. Waist measurement (>88cm women; 102cm men). 2. Hypertriglyceridemia (≥150mg/dL (≥1.69 mmmol/L)) 3. Low HDL (men <40mg/dL (<1.03 mmol/L)); women (<50mg/dL (<1.29 mmol/L)). 4. High blood pressure (systolic ≥130 mm Hg; diastolic ≥85 mm Hg). 5. High fasting glucose (≥110 mg/dL (≥6.10 mmol/L)) or currently using antidiabetic medication (insulin or oral agents) Method of assessing risk factor/exposure 1: Self-report Direct measurement Risk factor/exposure 2: inflammatory markers (Interleukin 6 (IL-6) and C-reactive protein (CRP) Method of assessing risk factor/exposure 2: Direct measurement Covariates/potential confounders adjusted for in analyses: Age Race Sex Educational level Smoking (current) Alcohol use (past year) Baseline cognitive status Method(s) of assessing cognitive status: 3MSE Informant interview?: No | 1) Follow-up rate: 2632/2949= 89% 164 died, 69 lost to follow-up, 84 no repeat cognitive testing. 2) Important baseline differences: Participants with Metabolic syndrome were more likely to be women, white, smoke, higher depression scores, higher BMI, + hx of MI, use statins and NSAIDs, and to have high markers of inflammation. 3) Outcome of interest #1 Cognitive impairment was defined as a change of 5 or more points at either follow-up visit on 3MS. 26% participants with metabolic sx and 21% no metabolic sx. Multivariate adjusted RR 1.66 (95% CI 1.02–1.41) 4) Outcome of interest #2 Individuals with Metabolic sx and high inflammation had increased likelihood of cognitive impairment (RR multivariate adjusted 1.66 (95% CI 1.19–2.32). Individuals with Metabolic syndrome and low inflammation did not have increased risk of cognitive impairment (RR multivariate adjusted 1.08 (95% CI 0.89–1.30) 5) Outcome of interest #3 Stratified multivariate random effects models showed that participants with metabolic sx and high inflammation had greater 4-year decline on 3MS compared to no Met sx (P=.04). Those with metabolic sx and low inflammation did not have greater decline (P=.44) | Comments: Findings support the hypothesis that metabolic syndrome contributes to cognitive impairment. A primary contributor to cognitive impairment due to metabolic syndrome appears to be inflammation. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Yasar, Corrada, Brookmeyer, et al., 2005 BLSA | Geographical location: USA, majority from Baltimore, MD – Washington, D.C. area Setting: Community Study design: Prospective cohort Number of participants enrolled: 1092 Duration of follow up: Mean yrs 11.0 Range 0.3 – 19.6 Time from risk factor assessment to final cognitive assessment: Ongoing assessment of meds throughout study. Some analyses required 2 to 4 year lag time between exposure and final cognitive outcome. | Age: Mean (SD): at last f/u 78.1 Range: 61.1 – 104.2 Sex: Female: 407 (37.3%) Male: 685 (62.7%) Race/ethnicity: [n (%)] White (93%) Other (7%) Baseline cognitive status: Non-demented Inclusion criteria: Participant in the Baltimore Longitudinal Study of Aging (BLSA > 60 years Exclusion criteria: NR | Risk factor/exposure 1: antihypertensives (ca channel blocker) Method of assessing risk factor/exposure 1: 1980–1990 self report for past two years, 1990 on pill bottle check Covariates/potential confounders adjusted for in analyses: Age, Sex Educational level Smoking, bp, hx heart problems Method(s) of assessing cognitive status: NINCDS-ADRDA DSM Informant interview?: Yes | 1) Follow-up rate: NR 2) Important baseline differences: baseline differences for ad versus not given, but not calcium channel blockers vs not. 3) Outcome of interest #1 RR for any CCB compared to non users 0.63 (0.31 – 1.28) for 2 yr lag 0.71 (0.33 – 1.51) for 4 yr lag 4) Outcome of interest #2 dhp-ccb user vs non user 0.30 (0.07 – 1.25) for 2 yr 0.45 (0.11 – 1.87) for 4 yr lag 5) Outcome of interest #3 non dhp –ccb user vs non user 0.82 (0.37 – 1.83) for 2 yr lag 0.82 (0.35 – 1.95) for 4 yr lag | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Partial 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell, but this appears to be secondary analyses so likely did not significantly influence results 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Can’t Tell 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Yesavage, Friedman, Ashford, et al., 2008 (Donepezil) | Geographical location: Palo Alto, USA Setting: Community Study design: RCT Test intervention Donepezil 5mg daily * 6 weeks, then 10mg daily for 46 weeks; dose reduction to 5mg allowed + 2 weeks cognitive training at weeks 13–14 Comparator intervention(s): Placebo + 2 weeks cognitive training at weeks 13–14 Number of participants enrolled: 168 (83 donepezil; 85 placebo) Duration of follow up: 1 year | Age: Mean (SD): 65.0 (7.4) donepezil; 64.3 (8.0) placebo Sex: [n (%)] Female: 88 Male: 80 Race/ethnicity: [n (%)] NR Baseline cognitive status: Normal-71% of participants MCI-29% of participants MMSE 28.6 (1.4) donepezil; 28.6 (1.2) placebo Inclusion criteria: Age 55–90 Good general health with normal B12, BP, thyroid, CBC, chemistries MMSE 24–30 Adequate auditory and visual acuity for neuropsych testing Exclusion criteria: Hachinski score >4 Hamilton depression rating scale -17 score >12 Significant neurological disease (other than suspected incipient AD) MDD, Alcohol or substance dependence in the past 2 years | Risk factor/exposure 1: Cognitive training: Provided to both groups. 2 hours daily * 10 days; visualization techniques and mnemonic training Method(s) of assessing cognitive status: Primary: Word list recall at 5 and 30 minutes Name-face recall Secondary: Logical Memory I score Logical Memory II score Symbol digit Digit Span Quality of life (Medical Outcomes Study Functioning and Well-Being Profile) Functional capacity (Everday problems test) | 1) Follow-up rate: Not given; random regression analysis used ITT principle Adherence: 89% of participants attended all 10 cognitive training sessions 2) Important baseline differences: More MCI APOE e4 carriers in placebo group (50% vs. 30%) 3) Outcome of interest #1 No significant effects at any timepoint (baseline, week 13 pre-cognitive training, week 14 post-cognitive training, or week 52) Mean change (SD) from baseline at week 52 [positive numbers = improvement] Word list recall: Donepezil 4.5 (4.0) Placebo 4.3 (4.2) Name-face: Donepezil 1.2 (2.7) Placebo 1.6 (2.7) 4) Outcome of interest #2 No significant differences in symbol digit or digit span; logical memory scores not reported No significant differences in quality of life measure or functional capacity 5) Outcome of interest #3 Dropouts for any reason in first 12 weeks: 15/83 (18.0%) donepezil vs. 6/85 (7.1%), p<0.05 Most common Adverse events: Donepezil vs. Placebo Muscle cramps: 19 vs. 1 Insomnia: 18 vs. 8 Abnormal dreams: 12 vs. 6 Nausea: 7 vs. 2 Only muscle cramps and insomnia statistically significant | Comments: No power calculation No participant flow (CONSORT) diagram presented No data on medication adherence given Quality assessment: For RCTs: 1) Baseline comparability? Yes except more APOE carriers in placebo group 2) Valid AD/cognitive outcomes assessment? Yes 3) Subjects/providers blind? Yes 4) Outcome assessors blind? Yes 5) Incomplete data adequately addressed?: Yes 6) Differential dropout rate < 10%? Can’t Tell 7) Overall dropout rate < 30%? Can’t Tell 8) Conflict of interest reported and insignificant? No, NIMH and VA funded 9) Randomization adequate? Yes 10) Allocation concealment adequate? Yes
Yoshitake, Kiyohara, Kato, et al., 1995 The Hisayama Study | Geographical location: Hisayama Town, Japan Setting: Community Study design: Prospective cohort Number of participants enrolled: 828 Duration of follow up: Seven years Time from risk factor assessment to final cognitive assessment: 7 years | Age: Mean (SD): For men: 73 (5.6) For women: 74 (6.1) Sex: [n (%)] Female: 494 (60%) Male: 334 (40%) Race/ethnicity: Japanese: 100% Baseline cognitive status: Non-demented Inclusion criteria: Resident of Hisayama Town Age ≥ 65 years Exclusion criteria: Demented | Risk factor/exposure 1: physical activity Method of assessing risk factor/exposure 1: Self-report “we defined the physically active group as those including daily exercise during the leisure period or moderate to severe physical activity at work.” Covariates/potential confounders adjusted for in analyses: [delete any from the list below that do not apply and add items as needed] Age Sex Method(s) of assessing cognitive status: [delete all that do not apply] 2-stage assessment; second stage based on clinical evaluation but assessment not well specified NINCDS-ADRDA DSM Informant interview?: No | 1) Follow-up rate: Initially 828. 214 died during f/u. f/u: 577 of 614 survivors (94.0%); 577 or 828 recruited (70%) 2) Important baseline differences: NR 3) Outcome of interest #1—AD “Age and a low score on Hasegawa’s dementia scale were significant risk factors for AD, and physical activity was a significant preventive factor.” RR (95% CI) Physically active: 0.20 (0.06–0.68) | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Can’t Tell 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? No, measure not cited and no validation 6) Validated method for ascertaining clinical outcomes? Can’t Tell 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Partial 11) Analytic methods appropriate? Yes
Yu, Ryan, Schaie, et al., 2009 Seattle Longitudina \| Study SLS | Geographical location: Pacific Northwest USA Setting: Other – health maintenance organization (HMO) Study design: Prospective cohort Number of participants enrolled: 626 Duration of follow up: 14 yrs Time from risk factor assessment to final cognitive assessment: 14 years | Age: Mean (SD): 53.20 (12.76) Range: 23 – 82 Sex: [n (%)] Female: 351 (56%) Male: 275 (44%) Race/ethnicity: [n (%)] White 601 (96%) Other 25 (4%) Baseline cognitive status: No exclusion based on cognitive status. 429 of the 502 participants over 60 years of age were given the neuropsychological battery. Of those, 3.7% were identified as having probable or definite dementia in 1998, representing 2.2% of the sample Inclusion criteria: SLS participants who met two criteria: (a) had completed three waves of data collection (in 1984, 1991, and 1998) (b) had no missing data for the independent variables and covariates Exclusion criteria: NR | Risk factor/exposure 1: leisure-time physical activity, leisure-time cognitive activity Method of assessing risk factor/exposure 1: Self-report survey: Life Complexity Inventory, LCI Risk factor/exposure 2: self-directed work, (work control, perceived autonomy and innovation) Method of assessing risk factor/exposure 2: Self-report Work Environment Inventory Risk Factor/Exposure: 3. Hypertension Method of assessing risk factor/exposure 3: The diagnosis was retrieved from participants’ HMO records Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Income Method(s) of assessing cognitive status: Other – [specify] Verbal memory (a) word fluency (b) immediate recall (c)delayed recall Inductive reasoning (a) Primary Mental Abilities, PMA, reasoning measure (b) Adult Development and Enrichment Project letter series, ADEPT-letter (c) word series and (d) Educational Testing Service number series Informant interview?: No | 1) Follow-up rate: 703 participants initially, 77 participants had missing data, so final sample of 626 participants, representing 38% of the total SLS sample in 1984 (n= 1,647). Average yearly attrition rate for the study sample was 2.71%. 2) Important baseline differences: Compared to the SLS total sample in 1984, the study sample was younger, but otherwise relatively equivalent 2) Outcome of interest #1 Work control was the only significant factor associated with verbal memory (p<0.05) 3) Outcome of interest #2 Work control was the only significant factor associated with inductive reasoning. Every increased unit of work control at the third wave was associated with a .14 t-score unit increase in inductive reasoning (p<0.05) | Comments: This study did not exclude participants who may have been impaired at the beginning of the study though the mean age of the cohort was 53 at entry. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Partial 2) Selection minimizes baseline differences in prognostic factors? Partial 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Can’t Tell 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Zandi, Sparks, Khachaturian, et al., 2005 Cache County Study | Geographical location: Cache County, UT Setting: Community Study design: Prospective cohort Number of participants enrolled: 4895 Duration of follow up: 3 yrs Time from risk factor assessment to final cognitive assessment: 3 yrs | Age: Mean (SD): 73.0 to 75.7 Sex: Female: 2797 (57%) Male: 2098 (43%) Race/ethnicity: NR Baseline cognitive status: Non-demented Inclusion criteria: ≥ 65 yo; permanent resident of Cache County, UT Exclusion criteria: Less than 65 years old Resident outside of Cache County, UT Dementia at baseline | Risk factor/exposure 1: Statin Method of assessing risk factor/exposure 1: Direct measurement – medication bottles Medical record - supplemented Risk factor/exposure 2: education; h/o stroke; HTN or DM; smoking Method of assessing risk factor/exposure 2: Self-report Covariates/potential confounders adjusted for in analyses: Age Sex Educational level Number of ApoE E4 alleles, age X e4 interaction h/o diabetes h/o hypertension Method(s) of assessing cognitive status: Other – Screen with modified 3MS or IQCODE. High risk by screening or clinical characteristics underwent detailed history, examination and neuropsych testing. NINCDS-ADRDA Informant interview?: Yes Text in the article reports that informant interviews were included when participants could not do 3MS. | 1) Follow-up rate: 3308/4540 (82.8%) 508 died 724 lost to f/u HR (95% CI) for AD – unadjusted Statin used 4AD/630 person years, HR 0.62 (0.19 to 1.48) No statin used 98/9522 person years, HR 1.0 (ref) Statin <= 3 years HR 0.49 (0.08 to 1.54) Statin > 3 years 0.43 (0.03 to 1.96) HR (95% CI) for AD – adjusted for age, sex, education, number o Apoe e4 alleles, age by e4 interaction, h/o HTN, h/o DM Statin used 4AD/630 person years, HR 1.19 (0.35 to 2.96) No statin used 98/9522 person years, HR 1.0 (ref) Statin <= 3 years HR 1.41 (0.23 to 4.70) Statin > 3 years 0.62 (0.03 to 2.92) | Comments: None Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Yes, Post-hoc 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Partial 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Zandi, Anthony, Hayden, et al., 2002 Cache | Geographical location: Cache County Utah. Setting: Community Study design: Prospective cohort Number of participants enrolled: 3511, 104 AD Duration of follow up: 3 years Time from risk factor assessment to final cognitive assessment: 3 years | Age: Range: 65 years and up Sex: [n (%)] Female: NR Male: NR Race/ethnicity: [n (%)] NR Baseline cognitive status: Normal Non-demented Inclusion criteria: Participating in the Cache County Study Exclusion criteria: Less than 65 years old | Risk factor/exposure 1: nsaids Method of assessing risk factor/exposure 1: Self-report And examination of pill bottles Covariates/potential confounders adjusted for in analyses: Age, squared deviation of age, Sex, apoe4, interaction age/apoE4 Educational level Baseline cognitive status Method(s) of assessing cognitive status: DSM Informant interview?: sometimes | 1) Follow-up rate: 83% of those without baseline dementia and still alive. 2) Important baseline differences: non asa nsaid users more likely to be women. 3) Outcome of interest #1 Use of nsaids for > 2 years associated with decreased risk of ad (but not current use unless use extended for 2 years prior to wave 1). Hr 0.45 (0.17–0.97) 4) Outcome of interest #2 Any lifetime use of nsaids almost associated with decreased risk of ad with hr 0.67 (o,40–1.06) | Comments: Question 1 waves 1 and 3 of Cache. Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? No 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Zandi, Anthony, Khachaturian, et al., 2004 Cache County Study | Geographical location: Logan, UT, USA Setting: Community Study design: Prospective cohort Number of participants enrolled: 3227 Duration of follow up: Est 3 yr Time from risk factor assessment to final cognitive assessment: Est 3 yr | Age: Mean (SD): mean range across exposure categories: 74.2–76.6 Sex: [n (%)] Female: mean % range across exposure categories: 53.6–64.0 Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented Inclusion criteria: Resident of Cache County, UT; age ≥ 65 yrs Exclusion criteria: None | Risk factor/exposure 1: Vitamins E and C, multivitamins, B- complex vitamins Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Sex Educational level APOE General health status Method(s) of assessing cognitive status: NINCDS-ADRDA DSM-3 revised Informant interview?: Yes | 1) Follow-up rate: 3227/ 4110 (denominator excludes those lost to f/u due to death) 2) Important baseline differences: User of Vitamin C or E were more likely to be female, younger, better educated and report better general health 3) Outcome of interest #1 Reduced risk of incident AD associated with combined Vitamin E and C use (HR=0.36; 0.09–0.99) No significant association between incident AD and Vitamin E alone, Vitamin C alone, multivitamin, or B-complex vitamins or any combination of these except for Vitamin E and C combined | Comments: Question 1 Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Yes 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Yes 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Yes 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes
Zunzunegui, Alvarado, Del Ser, et al., 2003 | Geographical location: Leganes, a suburb of Madrid, Spain Setting: Community Study design: Prospective cohort Number of participants enrolled: 557 analytical sample Duration of follow up: 4 yrs Time from risk factor assessment to final cognitive assessment: 4 yrs | Age: Mean (SD): NR Sex: [n (%)] Female: 264 (47.3) Male: 293 (52.7) Race/ethnicity: [n (%)] NR Baseline cognitive status: Non-demented (excluded individuals thought to be severely impaired based on cognitive screening score) Inclusion criteria: Stratified random sample of common- dwelling residents of Leganes, Spain > 65 years Exclusion criteria: Severely cognitively impaired defined as ≥ 5 errors on the SPMSQ, visually impaired | Risk factor/exposure 1: Social networks (number of monthly visual and phone contacts with friends and relatives (other than children)), social integration (membership in community associations, monthly attendance of religious services, visits to the community center) and social engagement (how frequently help, are useful, and play important roll in life of children, family and friends) Method of assessing risk factor/exposure 1: Self-report Covariates/potential confounders adjusted for in analyses: Age Educational level Sex Baseline cognitive status Depression Blood pressure Functional limitations Method(s) of assessing cognitive status: Other – decline on composite measure of cognitive tests. Severe decline defined as greater than 1 SD below the mean change. Mild decline defined as a change within 1 SD of the mean change. Informant interview?: No | 1) Follow-up rate: 557/964 completed f/u. 152 of the 964 were deceased, so f/u rate 557/812 (69%). 2) Important baseline differences: Men were more likely to be married whereas women were more likely to live alone or with family. Women reported less extensive networks than men. Attendance of religious services occurred more frequently among women than men. Women tended to be less engaged with friends than men. There were more women reporting cardiovascular morbidity (51.0%), high depressive symptomatology (40.5%), and functional limitations (22.7%), than men (36.0%, p < .001; 12.0%, p < .001; 8.0%, p < .001, respectively). There were no significant gender differences with respect to frequency of cognitive decline: 10.5% of women had severe and 24.6% mild decline, whereas 12.9% of men showed severe and 18.5% mild decline. 3) Outcome of interest #1 Increased risk of severe decline was only associated with no group membership in men, less social engagement with children in men, and less social engagement with friends in women. 4) Outcome of interest #2 The number of relatives seen at least monthly (p = 0.028) and the social integration index (p = 0.04) are significant predictors of cognitive decline for both sexes. Among women, engagement with friends predicts lower probability of cognitive decline. (interaction p= 0.19). Neither engagement with relatives or children was related to decline in this final model. Depression is associated with decline in men but not in women. (interaction p = 0.051). | Comments: Q2 – yes cat Dx Quality assessment: For observational studies: 1) Unbiased selection of the cohort? Yes 2) Selection minimizes baseline differences in prognostic factors? Yes 3) Sample size calculated/5% difference? Can’t Tell 4) Adequate description of the cohort? Yes 5) Validated method for ascertaining exposure? Partial 6) Validated method for ascertaining clinical outcomes? Yes 7) Outcome assessment blind to exposure? Can’t Tell 8) Adequate follow-up period? Yes 9) Completeness of follow-up? Partial 10) Analysis controls for confounding? Yes 11) Analytic methods appropriate? Yes (but limited description of how to interpret results makes interpreting results difficult)

## Articles Included in the Evidence Tables (in Alphabetical Order)

Aartsen MJ, Van Tilburg T, Smits CH, et al. Does widowhood affect memory performance of older persons?. Psychol Med. 2005;35(2):217-26. [pmid: 15841679].
Abbott RD, White LR, Ross GW, et al. Walking and dementia in physically capable elderly men. JAMA. 2004;292(12):1447-53. [pmid: 15383515].
Adapt Research Group. Lyketsos CG, Breitner JC, et al. Naproxen and celecoxib do not prevent AD in early results from a randomized controlled trial. Neurology. 2007;68(21):1800-8. [pmid: 17460158].
Aggarwal NT, Bienias JL, Bennett DA, et al. The relation of cigarette smoking to incident Alzheimer’s disease in a biracial urban community population. Neuroepidemiology. 2006;26(3):140-6. [pmid: 16493200].
Akbaraly TN, Hininger-Favier I, Carriere I, et al. Plasma selenium over time and cognitive decline in the elderly. Epidemiology. 2007;18(1):52-8. [pmid: 17130689].
Akbaraly TN, Portet F, Fustinoni S, et al. Leisure activities and the risk of dementia in the elderly: results from the Three-City Study. Neurology. 2009;73(11):854-61. [pmid: 19752452].
Akomolafe A, Beiser A, Meigs JB, et al. Diabetes mellitus and risk of developing Alzheimer disease: results from the Framingham Study. Arch Neurol. 2006;63(11):1551-5. [pmid: 17101823].
Alvarado BE, Zunzunegui MV, Del Ser T, et al. Cognitive decline is related to education and occupation in a Spanish elderly cohort. Aging Clin Exp Res. 2002;14(2):132-42. [pmid: 12092786].
Alves de Moraes S, Szklo M, Knopman D, et al. The relationship between temporal changes in blood pressure and changes in cognitive function: atherosclerosis risk in communities (ARIC) study. Prev Med. 2002;35(3):258-63. [pmid: 12202068].
Andel R, Crowe M, Pedersen NL, et al. Physical exercise at midlife and risk of dementia three decades later: a population-based study of Swedish twins. J Gerontol A Biol Sci Med Sci. 2008;63(1):62-6. [pmid: 18245762].
MRC/BHF Heart Protection Study of cholesterol lowering with simvastatin in 20,536 high-risk individuals: a randomised placebo-controlled trial. [summary for patients in Curr Cardiol Rep. 2002 Nov;4(6):486–7; PMID: 12379169]. Lancet. 2002;360(9326):7-22. [pmid: 12114036].
Applegate WB, Pressel S, Wittes J, et al. Impact of the treatment of isolated systolic hypertension on behavioral variables. Results from the systolic hypertension in the elderly program. Arch Intern Med. 1994;154(19):2154-60. [pmid: 7944835].
Arvanitakis Z, Grodstein F, Bienias JL, et al. Relation of NSAIDs to incident AD, change in cognitive function, and AD pathology. Neurology. 2008;70(23):2219-25. [pmid: 18519870].
Arvanitakis Z, Schneider J, Wilson R, et al. Statins, incident Alzheimer disease, change in cognitive function, and neuropathology. Neurology. 2008;70(19 Pt 2):1795-802. [pmid: 18199831].
Atti AR, Palmer K, Volpato S, et al. Late-life body mass index and dementia incidence: nine-year follow-up data from the Kungsholmen Project. J Am Geriatr Soc. 2008;56(1):111-6. [pmid: 18028342].
Ball K, Berch DB, Helmers KF, et al. Effects of cognitive training interventions with older adults: a randomized controlled trial. JAMA. 2002;288(18):2271-81. [pmid: 12425704].
Barnes DE, Alexopoulos GS, Lopez OL, et al. Depressive symptoms, vascular disease, and mild cognitive impairment: findings from the Cardiovascular Health Study. Arch Gen Psychiatry. 2006;63(3):273-9. [pmid: 16520432].
Barnes DE, Cauley JA, Lui LY, et al. Women who maintain optimal cognitive function into old age. J Am Geriatr Soc. 2007;55(2):259-64. [pmid: 17302664].
Barnes LL, Mendes de Leon CF, Wilson RS, et al. Social resources and cognitive decline in a population of older African Americans and whites. Neurology. 2004;63(12):2322-6. [pmid: 15623694].
Bernick C, Katz R, Smith N, et al. Statins and cognitive function in the elderly: the Cardiovascular Health Study. Neurology. 2005;65(9):1388-94. [pmid: 16275825].
Berr C, Balansard B, Arnaud J, et al. Cognitive decline is associated with systemic oxidative stress: the EVA study. Etude du Vieillissement Arteriel. J Am Geriatr Soc. 2000;48(10):1285-91. [pmid: 11037017].
Beydoun MA, Kaufman JS, Satia JA, et al. Plasma n-3 fatty acids and the risk of cognitive decline in older adults: the Atherosclerosis Risk in Communities Study. Am J Clin Nutr. 2007;85(4):1103-11. [pmid: 17413112].
Beydoun MA, Kaufman JS, Sloane PD, et al. n-3 Fatty acids, hypertension and risk of cognitive decline among older adults in the Atherosclerosis Risk in Communities (ARIC) study. Public Health Nutr. 2008;11(1):17-29. [pmid: 17625029].
Bierman EJ, Comijs HC, Rijmen F, et al. Anxiety symptoms and cognitive performance in later life: results from the longitudinal aging study Amsterdam. Aging Ment Health. 2008;12(4):517-23. [pmid: 18791901].
Blair CK, Folsom AR, Knopman DS, et al. APOE genotype and cognitive decline in a middle-aged cohort. Neurology. 2005;64(2):268-76. [pmid: 15668424].
Blasko I, Jellinger K, Kemmler G, et al. Conversion from cognitive health to mild cognitive impairment and Alzheimer's disease: prediction by plasma amyloid beta 42, medial temporal lobe atrophy and homocysteine. Neurobiol Aging. 2008;29(1):1-11. [pmid: 17055615].
Borenstein AR, Wu Y, Mortimer JA, et al. Developmental and vascular risk factors for Alzheimer's disease. Neurobiol Aging. 2005;26(3):325-34. [pmid: 15639310].
Bosma H, van Boxtel MP, Ponds RW, et al. Engaged lifestyle and cognitive function in middle and old-aged, non-demented persons: a reciprocal association?. Z Gerontol Geriatr. 2002;35(6):575-81. [pmid: 12491004].
Breitner JC, Haneuse SJ, Walker R, et al. Risk of dementia and AD with prior exposure to NSAIDs in an elderly community-based cohort. Neurology. 2009;72(22):1899-905. [pmid: 19386997].
Bretsky P, Guralnik JM, Launer L, et al. The role of APOE-epsilon4 in longitudinal cognitive decline: MacArthur Studies of Successful Aging. Neurology. 2003;60(7):1077-81. [pmid: 12682309].
Carmelli D, Swan GE, Reed T, et al. Midlife cardiovascular risk factors, ApoE, and cognitive decline in elderly male twins. Neurology. 1998;50(6):1580-5. [pmid: 9633697].
Cherbuin N, Reglade-Meslin C, Kumar R, et al. Risk factors of transition from normal cognition to mild cognitive disorder: the PATH through Life Study. Dement Geriatr Cogn Disord. 2009;28(1):47-55. [pmid: 19628940].
Christensen H, Batterham PJ, Mackinnon AJ, et al. The association of APOE genotype and cognitive decline in interaction with risk factors in a 65–69 year old community sample. BMC Geriatr. 2008;8:14. [pmid: 18620605].
Christensen H, Henderson AS, Korten AE, et al. ICD-10 mild cognitive disorder: its outcome three years later. Int J Geriatr Psychiatry. 1997;12(5):581-6. [pmid: 9193969].
Clarke R, Birks J, Nexo E, et al. Low vitamin B-12 status and risk of cognitive decline in older adults. Am J Clin Nutr. 2007;86(5):1384-91. [pmid: 17991650].
Comijs HC, Kriegsman DM, Dik MG, et al. Somatic chronic diseases and 6-year change in cognitive functioning among older persons. Arch Gerontol Geriatr. 2009;48(2):191-6. [pmid: 18299158].
Commenges D, Scotet V, Renaud S, et al. Intake of flavonoids and risk of dementia. Eur J Epidemiol. 2000;16(4):357-63. [pmid: 10959944].
Cornelius C, Fastbom J, Winblad B, et al. Aspirin, NSAIDs, risk of dementia, and influence of the apolipoprotein E epsilon 4 allele in an elderly population. Neuroepidemiology. 2004;23(3):135-43. [pmid: 15084783].
Dai Q, Borenstein AR, Wu Y, et al. Fruit and vegetable juices and Alzheimer's disease: the Kame Project. Am J Med. 2006;119(9):751-9. [pmid: 16945610].
de Lau LM, Smith AD, Refsum H, et al. Plasma vitamin B12 status and cerebral white-matter lesions. J Neurol Neurosurg Psychiatry. 2009;80(2):149-57. [pmid: 18977824].
DeKosky ST, Williamson JD, Fitzpatrick AL, et al. Ginkgo biloba for prevention of dementia: a randomized controlled trial. JAMA. 2008;300(19):2253-62. [pmid: 19017911].
Devore EE, Grodstein F, van Rooij FJ, et al. Dietary intake of fish and omega-3 fatty acids in relation to long-term dementia risk. Am J Clin Nutr. 2009;90(1):170-6. [pmid: 19474131].
Devore EE, Kang JH, Okereke O, et al. Physical activity levels and cognition in women with type 2 diabetes. Am J Epidemiol. 2009;170(8):1040-7. [pmid: 19729385].
Dik MG, Jonker C, Bouter LM, et al. APOE-epsilon4 is associated with memory decline in cognitively impaired elderly. Neurology. 2000;54(7):1492-7. [pmid: 10751265].
Dodge HH, Zitzelberger T, Oken BS, et al. A randomized placebo-controlled trial of Ginkgo biloba for the prevention of cognitive decline. Neurology. 2008;70(19 Pt 2):1809-17. [pmid: 18305231].
Doody RS, Ferris SH, Salloway S, et al. Donepezil treatment of patients with MCI: a 48-week randomized, placebo-controlled trial. Neurology. 2009;72(18):1555-61. [pmid: 19176895].
Dufouil C, Alperovitch A, Ducros V, et al. Homocysteine, white matter hyperintensities, and cognition in healthy elderly people. Ann Neurol. 2003;53(2):214-21. [pmid: 12557288].
Dufouil C, Fuhrer R, Dartigues JF, et al. Longitudinal analysis of the association between depressive symptomatology and cognitive deterioration. Am J Epidemiol. 1996;144(7):634-41. [pmid: 8823058].
Dullemeijer C, Durga J, Brouwer IA, et al. n 3 fatty acid proportions in plasma and cognitive performance in older adults. Am J Clin Nutr. 2007;86(5):1479-85. [pmid: 17991662].
Engelhart MJ, Geerlings MI, Ruitenberg A, et al. Dietary intake of antioxidants and risk of Alzheimer disease. JAMA. 2002;287(24):3223-9. [pmid: 12076218].
Evans DA, Hebert LE, Beckett LA, et al. Education and other measures of socioeconomic status and risk of incident Alzheimer disease in a defined population of older persons. Arch Neurol. 1997;54(11):1399-405. [pmid: 9362989].
Everson-Rose SA, Mendes de Leon CF, Bienias JL, et al. Early life conditions and cognitive functioning in later life. Am J Epidemiol. 2003;158(11):1083-9. [pmid: 14630604].
Feart C, Samieri C, Rondeau V, et al. Adherence to a Mediterranean diet, cognitive decline, and risk of dementia. JAMA. 2009;302(6):638-48. [pmid: 19671905].
Fillenbaum GG, Kuchibhatla MN, Hanlon JT, et al. Dementia and Alzheimer's disease in community-dwelling elders taking vitamin C and/or vitamin E. Ann Pharmacother. 2005;39(12):2009-14. [pmid: 16227448].
Fitzpatrick AL, Kuller LH, Lopez OL, et al. Midlife and late-life obesity and the risk of dementia: cardiovascular health study. Arch Neurol. 2009;66(3):336-42. [pmid: 19273752].
Fotuhi M, Zandi PP, Hayden KM, et al. Better cognitive performance in elderly taking antioxidant vitamins E and C supplements in combination with nonsteroidal anti-inflammatory drugs: the Cache County Study. Alzheimers Dement. 2008;4(3):223-7. [pmid: 18631971].
Fratiglioni L, Wang HX, Ericsson K, et al. Influence of social network on occurrence of dementia: a community-based longitudinal study. Lancet. 2000;355(9212):1315-9. [pmid: 10776744].
Freitag MH, Peila R, Masaki K, et al. Midlife pulse pressure and incidence of dementia: the Honolulu-Asia Aging Study. Stroke. 2006;37(1):33-7. [pmid: 16339468].
Gallacher J, Bayer A, Fish M, et al. Does anxiety affect risk of dementia? Findings from the Caerphilly Prospective Study. Psychosom Med. 2009;71(6):659-66. [pmid: 19553290].
Gatz JL, Tyas SL, St John P, et al. Do depressive symptoms predict Alzheimer's disease and dementia?. J Gerontol A Biol Sci Med Sci. 2005;60(6):744-7. [pmid: 15983177].
Geda YE, Knopman DS, Mrazek DA, et al. Depression, apolipoprotein E genotype, and the incidence of mild cognitive impairment: a prospective cohort study. Arch Neurol. 2006;63(3):435-40. [pmid: 16533972].
Geerlings MI, den Heijer T, Koudstaal PJ, et al. History of depression, depressive symptoms, and medial temporal lobe atrophy and the risk of Alzheimer disease. Neurology. 2008;70(15):1258-64. [pmid: 18391157].
Glynn RJ, Beckett LA, Hebert LE, et al. Current and remote blood pressure and cognitive decline. JAMA. 1999;281(5):438-45. [pmid: 9952204].
Gonzalez HM, Bowen ME, Fisher GG. Memory decline and depressive symptoms in a nationally representative sample of older adults: the Health and Retirement Study (1998–2004). Dement Geriatr Cogn Disord. 2008;25(3):266-71. [pmid: 18270489].
Graves AB, Rajaram L, Bowen JD, et al. Cognitive decline and Japanese culture in a cohort of older Japanese Americans in King County, WA: the Kame Project. J Gerontol B Psychol Sci Soc Sci. 1999;54(3):S154-61. [pmid: 10363046].
Gray SL, Anderson ML, Crane PK, et al. Antioxidant vitamin supplement use and risk of dementia or Alzheimer's disease in older adults. J Am Geriatr Soc. 2008;56(2):291-5. [pmid: 18047492].
Green AF, Rebok G, Lyketsos CG. Influence of social network characteristics on cognition and functional status with aging. Int J Geriatr Psychiatry. 2008;23(9):972-8. [pmid: 18449952].
Grodstein F, Skarupski KA, Bienias JL, et al. Anti-inflammatory agents and cognitive decline in a bi-racial population. Neuroepidemiology. 2008;30(1):45-50. [pmid: 18259082].
Guo Z, Fratiglioni L, Viitanen M, et al. Apolipoprotein E genotypes and the incidence of Alzheimer's disease among persons aged 75 years and older: variation by use of antihypertensive medication?. Am J Epidemiol. 2001;153(3):225-31. [pmid: 11157409].
Haag M, Hofman A, Koudstaal P, et al. Statins are associated with a reduced risk of Alzheimer disease regardless of lipophilicity. The Rotterdam Study. J Neurol Neurosurg Psychiatry. 2009;80(1):13-7. [pmid: 18931004].
Haag MD, Hofman A, Koudstaal PJ, et al. Duration of antihypertensive drug use and risk of dementia: A prospective cohort study. Neurology. 2009;72(20):1727-34. [pmid: 19228584].
Haan MN, Shemanski L, Jagust WJ, et al. The role of APOE epsilon4 in modulating effects of other risk factors for cognitive decline in elderly persons. JAMA. 1999;282(1):40-6. [pmid: 10404910].
Hakansson K, Rovio S, Helkala EL, et al. Association between mid-life marital status and cognitive function in later life: population based cohort study. BMJ. 2009;339:b2462. [pmid: 19574312].
Hayden KM, Zandi PP, Khachaturian AS, et al. Does NSAID use modify cognitive trajectories in the elderly? The Cache County study. Neurology. 2007;69(3):275-82. [pmid: 17636065].
Hebert LE, Scherr PA, Bennett DA, et al. Blood pressure and late-life cognitive function change: a biracial longitudinal population study. Neurology. 2004;62(11):2021-4. [pmid: 15184608].
Hee Kang J, Cook N, Manson J, et al. Low dose aspirin and cognitive function in the women's health study cognitive cohort. BMJ. 2007;334(7601):987. [pmid: 17468120].
Hee Kang J, Grodstein F. Regular use of nonsteroidal anti-inflammatory drugs and cognitive function in aging women. Neurology. 2003;60(10):1591-7. [pmid: 12771247].
Helmer C, Damon D, Letenneur L, et al. Marital status and risk of Alzheimer's disease: a French population-based cohort study. Neurology. 1999;53(9):1953-8. [pmid: 10599764].
Ho RC, Niti M, Yap KB, et al. Metabolic syndrome and cognitive decline in chinese older adults: results from the singapore longitudinal ageing studies. Am J Geriatr Psychiatry. 2008;16(6):519-22. [pmid: 18515697].
Ho SC, Woo J, Sham A, et al. A 3-year follow-up study of social, lifestyle and health predictors of cognitive impairment in a Chinese older cohort. Int J Epidemiol. 2001;30(6):1389-96. [pmid: 11821352].
Holtzman RE, Rebok GW, Saczynski JS, et al. Social network characteristics and cognition in middle-aged and older adults. J Gerontol B Psychol Sci Soc Sci. 2004;59(6):P278-84. [pmid: 15576855].
Huang TL, Zandi PP, Tucker KL, et al. Benefits of fatty fish on dementia risk are stronger for those without APOE epsilon4. Neurology. 2005;65(9):1409-14. [pmid: 16275829].
Hughes TF, Andel R, Small BJ, et al. Midlife Fruit and Vegetable Consumption and Risk of Dementia in Later Life in Swedish Twins. Am J Geriatr Psychiatry. 2009.
Hughes TF, Borenstein AR, Schofield E, et al. Association between late-life body mass index and dementia: The Kame Project. Neurology. 2009;72(20):1741-6. [pmid: 19451529].
Insel KC, Palmer RF, Stroup-Benham CA, et al. Association between change in systolic blood pressure and cognitive decline among elderly Mexican Americans: data from the Hispanic established population for epidemiology study of the elderly. Exp Aging Res. 2005;31(1):35-54. [pmid: 15842072].
in't Veld BA, Ruitenberg A, Hofman A, et al. Antihypertensive drugs and incidence of dementia: the Rotterdam Study. Neurobiol Aging. 2001;22(3):407-12. [pmid: 11378246].
Irie F, Fitzpatrick AL, Lopez OL, et al. Enhanced risk for Alzheimer disease in persons with type 2 diabetes and APOE epsilon4: the Cardiovascular Health Study Cognition Study. Arch Neurol. 2008;65(1):89-93. [pmid: 18195144].
Irie F, Masaki KH, Petrovitch H, et al. Apolipoprotein E epsilon4 allele genotype and the effect of depressive symptoms on the risk of dementia in men: the Honolulu-Asia Aging Study. Arch Gen Psychiatry. 2008;65(8):906-12. [pmid: 18678795].
Jonker C, Comijs HC, Smit JH. Does aspirin or other NSAIDs reduce the risk of cognitive decline in elderly persons? Results from a population-based study. Neurobiol Aging. 2003;24(4):583-8. [pmid: 12714115].
Kado DM, Karlamangla AS, Huang MH, et al. Homocysteine versus the vitamins folate, B6, and B12 as predictors of cognitive function and decline in older high-functioning adults: MacArthur Studies of Successful Aging. Am J Med. 2005;118(2):161-7. [pmid: 15694902].
Kalmijn S, Feskens EJ, Launer LJ, et al. Longitudinal study of the effect of apolipoprotein e4 allele on the association between education and cognitive decline in elderly men. BMJ. 1997;314(7073):34-5. [pmid: 9001477].
Kalmijn S, Feskens EJ, Launer LJ, et al. Polyunsaturated fatty acids, antioxidants, and cognitive function in very old men. Am J Epidemiol. 1997;145(1):33-41. [pmid: 8982020].
Kalmijn S, Launer LJ, Lindemans J, et al. Total homocysteine and cognitive decline in a community-based sample of elderly subjects: the Rotterdam Study. Am J Epidemiol. 1999;150(3):283-9. [pmid: 10430233].
Kalmijn S, Launer LJ, Ott A, et al. Dietary fat intake and the risk of incident dementia in the Rotterdam Study. Ann Neurol. 1997;42(5):776-82. [pmid: 9392577].
Kang JH, Ascherio A, Grodstein F. Fruit and vegetable consumption and cognitive decline in aging women. Ann Neurol. 2005;57(5):713-20. [pmid: 15852398].
Kang JH, Cook N, Manson J, et al. A trial of B vitamins and cognitive function among women at high risk of cardiovascular disease. Am J Clin Nutr. 2008;88(6):1602-10. [pmid: 19064521].
Kang JH, Cook N, Manson J, et al. A randomized trial of vitamin E supplementation and cognitive function in women. Arch Intern Med. 2006;166(22):2462-8. [pmid: 17159011].
Kang JH, Cook NR, Manson JE, et al. Vitamin E, vitamin C, beta carotene, and cognitive function among women with or at risk of cardiovascular disease: The Women's Antioxidant and Cardiovascular Study. Circulation. 2009;119(21):2772-80. [pmid: 19451353].
Kang JH, Grodstein F. Plasma carotenoids and tocopherols and cognitive function: a prospective study. Neurobiol Aging. 2008;29(9):1394-403. [pmid: 17433501].
Karlamangla AS, Miller-Martinez D, Aneshensel CS, et al. Trajectories of cognitive function in late life in the United States: demographic and socioeconomic predictors. Am J Epidemiol. 2009;170(3):331-42. [pmid: 19605514].
Khachaturian AS, Zandi PP, Lyketsos CG, et al. Antihypertensive medication use and incident Alzheimer disease: the Cache County Study. Arch Neurol. 2006;63(5):686-92. [pmid: 16533956].
Kivipelto M, Helkala EL, Laakso MP, et al. Midlife vascular risk factors and Alzheimer's disease in later life: longitudinal, population based study. BMJ. 2001;322(7300):1447-51. [pmid: 11408299].
Kivipelto M, Ngandu T, Fratiglioni L, et al. Obesity and vascular risk factors at midlife and the risk of dementia and Alzheimer disease. Arch Neurol. 2005;62(10):1556-60. [pmid: 16216938].
Knopman D, Boland LL, Mosley T, et al. Cardiovascular risk factors and cognitive decline in middle-aged adults. Neurology. 2001;56(1):42-8. [pmid: 11148234].
Knopman DS, Mosley TH, Catellier DJ, et al. Fourteen-year longitudinal study of vascular risk factors, APOE genotype, and cognition: the ARIC MRI Study. Alzheimers Dement. 2009;5(3):207-14. [pmid: 19362884].
Koster A, Penninx BW, Bosma H, et al. Socioeconomic differences in cognitive decline and the role of biomedical factors. Ann Epidemiol. 2005;15(8):564-71. [pmid: 15922627].
Kritz-Silverstein D, von Muhlen D, Laughlin GA, et al. Effects of dehydroepiandrosterone supplementation on cognitive function and quality of life: the DHEA and Well-Ness (DAWN) Trial. J Am Geriatr Soc. 2008;56(7):1292-8. [pmid: 18482290].
Kroger E, Verreault R, Carmichael PH, et al. Omega-3 fatty acids and risk of dementia: the Canadian Study of Health and Aging. Am J Clin Nutr. 2009;90(1):184-92. [pmid: 19474137].
Kuo HK, Jones RN, Milberg WP, et al. Effect of blood pressure and diabetes mellitus on cognitive and physical functions in older adults: a longitudinal analysis of the advanced cognitive training for independent and vital elderly cohort. J Am Geriatr Soc. 2005;53(7):1154-61. [pmid: 16108933].
Laitinen MH, Ngandu T, Rovio S, et al. Fat intake at midlife and risk of dementia and Alzheimer's disease: a population-based study. Dement Geriatr Cogn Disord. 2006;22(1):99-107. [pmid: 16710090].
Larson EB, Wang L, Bowen JD, et al. Exercise is associated with reduced risk for incident dementia among persons 65 years of age and older. Ann Intern Med. 2006;144(2):73-81. [pmid: 16418406].
Launer LJ, Ross GW, Petrovitch H, et al. Midlife blood pressure and dementia: the Honolulu-Asia aging study. Neurobiol Aging. 2000;21(1):49-55. [pmid: 10794848].
Laurin D, Masaki KH, Foley DJ, et al. Midlife dietary intake of antioxidants and risk of late-life incident dementia: the Honolulu-Asia Aging Study. Am J Epidemiol. 2004;159(10):959-67. [pmid: 15128608].
Laurin D, Verreault R, Lindsay J, et al. Physical activity and risk of cognitive impairment and dementia in elderly persons. Arch Neurol. 2001;58(3):498-504. [pmid: 11255456].
Lautenschlager NT, Cox KL, Flicker L, et al. Effect of physical activity on cognitive function in older adults at risk for Alzheimer disease: a randomized trial. JAMA. 2008;300(9):1027-37. [pmid: 18768414].
Lee S, Buring JE, Cook NR, et al. The relation of education and income to cognitive function among professional women. Neuroepidemiology. 2006;26(2):93-101. [pmid: 16352912].
Lee S, Kawachi I, Berkman LF, et al. Education, other socioeconomic indicators, and cognitive function. Am J Epidemiol. 2003;157(8):712-20. [pmid: 12697575].
Li G, Higdon R, Kukull WA, et al. Statin therapy and risk of dementia in the elderly: a community-based prospective cohort study. Neurology. 2004;63(9):1624-8. [pmid: 15534246].
Li G, Rhew IC, Shofer JB, et al. Age-varying association between blood pressure and risk of dementia in those aged 65 and older: a community-based prospective cohort study. J Am Geriatr Soc. 2007;55(8):1161-7. [pmid: 17661953].
Lindsay J, Laurin D, Verreault R, et al. Risk factors for Alzheimer's disease: a prospective analysis from the Canadian Study of Health and Aging. Am J Epidemiol. 2002;156(5):445-53. [pmid: 12196314].
Lu PH, Edland SD, Teng E, et al. Donepezil delays progression to AD in MCI subjects with depressive symptoms. Neurology. 2009;72(24):2115-21. [pmid: 19528519].
Luchsinger JA, Honig LS, Tang MX, et al. Depressive symptoms, vascular risk factors, and Alzheimer's disease. Int J Geriatr Psychiatry. 2008;23(9):922-8. [pmid: 18327871].
Luchsinger JA, Reitz C, Honig LS, et al. Aggregation of vascular risk factors and risk of incident Alzheimer disease. Neurology. 2005;65(4):545-51. [pmid: 16116114].
Luchsinger JA, Tang MX, Miller J, et al. Relation of higher folate intake to lower risk of Alzheimer disease in the elderly. Arch Neurol. 2007;64(1):86-92. [pmid: 17210813].
Luchsinger JA, Tang MX, Shea S, et al. Caloric intake and the risk of Alzheimer disease. Arch Neurol. 2002;59(8):1258-63. [pmid: 12164721].
Luchsinger JA, Tang MX, Shea S, et al. Antioxidant vitamin intake and risk of Alzheimer disease. Arch Neurol. 2003;60(2):203-8. [pmid: 12580704].
Luchsinger JA, Tang MX, Shea S, et al. Plasma homocysteine levels and risk of Alzheimer disease. Neurology. 2004;62(11):1972-6. [pmid: 15184599].
Lytle ME, Vander Bilt J, Pandav RS, et al. Exercise level and cognitive decline: the MoVIES project. Alzheimer Dis Assoc Disord. 2004;18(2):57-64. [pmid: 15249848].
Manly JJ, Schupf N, Tang MX, et al. Cognitive decline and literacy among ethnically diverse elders. J Geriatr Psychiatry Neurol. 2005;18(4):213-7. [pmid: 16306242].
Martin BK, Szekely C, Brandt J, et al. Cognitive function over time in the Alzheimer's Disease Anti-inflammatory Prevention Trial (ADAPT): results of a randomized, controlled trial of naproxen and celecoxib. Arch Neurol. 2008;65(7):896-905. [pmid: 18474729].
Masaki KH, Losonczy KG, Izmirlian G, et al. Association of vitamin E and C supplement use with cognitive function and dementia in elderly men. Neurology. 2000;54(6):1265-72. [pmid: 10746596].
Maxwell CJ, Hicks MS, Hogan DB, et al. Supplemental use of antioxidant vitamins and subsequent risk of cognitive decline and dementia. Dement Geriatr Cogn Disord. 2005;20(1):45-51. [pmid: 15832036].
McMahon JA, Green TJ, Skeaff CM, et al. A controlled trial of homocysteine lowering and cognitive performance. N Engl J Med. 2006;354(26):2764-72. [pmid: 16807413].
McNeill G, Avenell A, Campbell MK, et al. Effect of multivitamin and multimineral supplementation on cognitive function in men and women aged 65 years and over: a randomised controlled trial. Nutr J. 2007;6:10. [pmid: 17474991].
Mehta KM, Ott A, Kalmijn S, et al. Head trauma and risk of dementia and Alzheimer's disease: The Rotterdam Study. Neurology. 1999;53(9):1959-62. [pmid: 10599765].
Morris MC, Beckett LA, Scherr PA, et al. Vitamin E and vitamin C supplement use and risk of incident Alzheimer disease. Alzheimer Dis Assoc Disord. 1998;12(3):121-6. [pmid: 9772012].
Morris MC, Evans DA, Bienias JL, et al. Dietary niacin and the risk of incident Alzheimer's disease and of cognitive decline. J Neurol Neurosurg Psychiatry. 2004;75(8):1093-9. [pmid: 15258207].
Morris MC, Evans DA, Bienias JL, et al. Dietary fats and the risk of incident Alzheimer disease. Arch Neurol. 2003;60(2):194-200. [pmid: 12580703].
Morris MC, Evans DA, Bienias JL, et al. Dietary intake of antioxidant nutrients and the risk of incident Alzheimer disease in a biracial community study. JAMA. 2002;287(24):3230-7. [pmid: 12076219].
Morris MC, Evans DA, Bienias JL, et al. Consumption of fish and n-3 fatty acids and risk of incident Alzheimer disease. Arch Neurol. 2003;60(7):940-6. [pmid: 12873849].
Morris MC, Evans DA, Bienias JL, et al. Dietary folate and vitamin B12 intake and cognitive decline among community-dwelling older persons. Arch Neurol. 2005;62(4):641-5. [pmid: 15824266].
Morris MC, Evans DA, Bienias JL, et al. Vitamin E and cognitive decline in older persons. Arch Neurol. 2002;59(7):1125-32. [pmid: 12117360].
Morris MC, Evans DA, Bienias JL, et al. Dietary fat intake and 6-year cognitive change in an older biracial community population. Neurology. 2004;62(9):1573-9. [pmid: 15136684].
Morris MC, Evans DA, Schneider JA, et al. Dietary folate and vitamins B-12 and B-6 not associated with incident Alzheimer's disease. J Alzheimers Dis. 2006;9(4):435-43. [pmid: 16917153].
Morris MC, Evans DA, Tangney CC, et al. Dietary copper and high saturated and trans fat intakes associated with cognitive decline. Arch Neurol. 2006;63(8):1085-8. [pmid: 16908733].
Morris MC, Evans DA, Tangney CC, et al. Associations of vegetable and fruit consumption with age-related cognitive change. Neurology. 2006;67(8):1370-6. [pmid: 17060562].
Morris MC, Evans DA, Tangney CC, et al. Relation of the tocopherol forms to incident Alzheimer disease and to cognitive change. Am J Clin Nutr. 2005;81(2):508-14. [pmid: 15699242].
Morris MC, Scherr PA, Hebert LE, et al. Association of incident Alzheimer disease and blood pressure measured from 13 years before to 2 years after diagnosis in a large community study. Arch Neurol. 2001;58(10):1640-6. [pmid: 11594923].
Muller M, Tang MX, Schupf N, et al. Metabolic syndrome and dementia risk in a multiethnic elderly cohort. Dement Geriatr Cogn Disord. 2007;24(3):185-92. [pmid: 17641531].
Muniz-Terrera G, Matthews F, Dening T, et al. Education and trajectories of cognitive decline over 9 years in very old people: methods and risk analysis. Age Ageing. 2009;38(3):277-82. [pmid: 19252209].
Ng TP, Niti M, Zaw MH, et al. Depressive symptoms and incident cognitive impairment in cognitively well-functioning older men and women. J Am Geriatr Soc. 2009;57(6):1058-63. [pmid: 19467145].
Ngandu T, von Strauss E, Helkala EL, et al. Education and dementia: what lies behind the association?. Neurology. 2007;69(14):1442-50. [pmid: 17909157].
Nickelsen T, Lufkin EG, Riggs BL, et al. Raloxifene hydrochloride, a selective estrogen receptor modulator: safety assessment of effects on cognitive function and mood in postmenopausal women. Psychoneuroendocrinology. 1999;24(1):115-28. [pmid: 10098223].
Niti M, Yap KB, Kua EH, et al. APOE-epsilon4, depressive symptoms, and cognitive decline in Chinese older adults: Singapore Longitudinal Aging Studies. J Gerontol A Biol Sci Med Sci. 2009;64(2):306-11. [pmid: 19181718].
Niti M, Yap KB, Kua EH, et al. Physical, social and productive leisure activities, cognitive decline and interaction with APOE-epsilon 4 genotype in Chinese older adults. Int Psychogeriatr. 2008;20(2):237-51. [pmid: 18190728].
Okereke OI, Kang JH, Cook NR, et al. Type 2 diabetes mellitus and cognitive decline in two large cohorts of community-dwelling older adults. J Am Geriatr Soc. 2008;56(6):1028-36. [pmid: 18384580].
Packard C, Westendorp R, Stott D, et al. Association between apolipoprotein E4 and cognitive decline in elderly adults. J Am Geriatr Soc. 2007;55(11):1777-85. [pmid: 17979899].
Panza F, D'Introno A, Colacicco AM, et al. Depressive symptoms, vascular risk factors and mild cognitive impairment. The Italian longitudinal study on aging. Dement Geriatr Cogn Disord. 2008;25(4):336-46. [pmid: 18319599].
Paterniti S, Verdier-Taillefer MH, Dufouil C, et al. Depressive symptoms and cognitive decline in elderly people. Longitudinal study. Br J Psychiatry. 2002;181:406-10. [pmid: 12411266].
Peila R, White LR, Masaki K, et al. Reducing the risk of dementia: efficacy of long-term treatment of hypertension. Stroke. 2006;37(5):1165-70. [pmid: 16601212].
Petersen RC, Thomas RG, Grundman M, et al. Vitamin E and donepezil for the treatment of mild cognitive impairment. N Engl J Med. 2005;352(23):2379-88. [pmid: 15829527].
Plassman BL, Havlik RJ, Steffens DC, et al. Documented head injury in early adulthood and risk of Alzheimer's disease and other dementias. Neurology. 2000;55(8):1158-66. [pmid: 11071494].
Podewils LJ, Guallar E, Kuller LH, et al. Physical activity, APOE genotype, and dementia risk: findings from the Cardiovascular Health Cognition Study. Am J Epidemiol. 2005;161(7):639-51. [pmid: 15781953].
Posner HB, Tang MX, Luchsinger J, et al. The relationship of hypertension in the elderly to AD, vascular dementia, and cognitive function. Neurology. 2002;58(8):1175-81. [pmid: 11971083].
Potter GG, Plassman BL, Helms MJ, et al. Occupational characteristics and cognitive performance among elderly male twins. Neurology. 2006;67(8):1377-82. [pmid: 17060563].
Price JF, Stewart MC, Deary IJ, et al. Low dose aspirin and cognitive function in middle aged to elderly adults: randomised controlled trial. BMJ. 2008;337:a1198. [pmid: 18762476].
Prince M, Cullen M, Mann A. Risk factors for Alzheimer's disease and dementia: a case-control study based on the MRC elderly hypertension trial. Neurology. 1994;44(1):97-104. [pmid: 8290099].
Prince M, Rabe-Hesketh S, Brennan P. Do antiarthritic drugs decrease the risk for cognitive decline? An analysis based on data from the MRC treatment trial of hypertension in older adults. Neurology. 1998;50(2):374-9. [pmid: 9484356].
Prince MJ, Bird AS, Blizard RA, et al. Is the cognitive function of older patients affected by antihypertensive treatment? Results from 54 months of the Medical Research Council's trial of hypertension in older adults. BMJ. 1996;312(7034):801-5. [pmid: 8608285].
Qiu C, Winblad B, Fastbom J, et al. Combined effects of APOE genotype, blood pressure, and antihypertensive drug use on incident AD. Neurology. 2003;61(5):655-60. [pmid: 12963757].
Ravaglia G, Forti P, Lucicesare A, et al. Physical activity and dementia risk in the elderly: findings from a prospective Italian study. Neurology. 2008;70(19 Pt 2):1786-94. [pmid: 18094335].
Ravaglia G, Forti P, Lucicesare A, et al. Prevalent depressive symptoms as a risk factor for conversion to mild cognitive impairment in an elderly Italian cohort. Am J Geriatr Psychiatry. 2008;16(10):834-43. [pmid: 18827230].
Ravaglia G, Forti P, Maioli F, et al. Homocysteine and folate as risk factors for dementia and Alzheimer disease. Am J Clin Nutr. 2005;82(3):636-43. [pmid: 16155278].
Ravaglia G, Forti P, Maioli F, et al. Risk factors for dementia: data from the Conselice study of brain aging. Arch Gerontol Geriatr. 2007;44(Suppl 1):311-20. [pmid: 17317467].
Rea T, Breitner J, Psaty B, et al. Statin use and the risk of incident dementia: the Cardiovascular Health Study. Arch Neurol. 2005;62(7):1047-51. [pmid: 16009757].
Reitz C, den Heijer T, van Duijn C, et al. Relation between smoking and risk of dementia and Alzheimer disease: the Rotterdam Study. Neurology. 2007;69(10):998-1005. [pmid: 17785668].
Reitz C, Luchsinger J, Tang MX, et al. Impact of plasma lipids and time on memory performance in healthy elderly without dementia. Neurology. 2005;64(8):1378-83. [pmid: 15851727].
Reitz C, Tang MX, Manly J, et al. Hypertension and the risk of mild cognitive impairment. Arch Neurol. 2007;64(12):1734-40. [pmid: 18071036].
Reitz C, Tang M-X, Luchsinger J, et al. Relation of plasma lipids to Alzheimer disease and vascular dementia. Arch Neurol. 2004;61(5):705-14. [pmid: 15148148].
Rondeau V, Jacqmin-Gadda H, Commenges D, et al. Aluminum and silica in drinking water and the risk of Alzheimer's disease or cognitive decline: findings from 15-year follow-up of the PAQUID cohort. Am J Epidemiol. 2009;169(4):489-96. [pmid: 19064650].
Rovio S, Kareholt I, Helkala EL, et al. Leisure-time physical activity at midlife and the risk of dementia and Alzheimer's disease. Lancet Neurol. 2005;4(11):705-11. [pmid: 16239176].
Rovio S, Kareholt I, Viitanen M, et al. Work-related physical activity and the risk of dementia and Alzheimer's disease. Int J Geriatr Psychiatry. 2007;22(9):874-82. [pmid: 17721898].
Ryan J, Carriere I, Scali J, et al. Life-time estrogen exposure and cognitive functioning in later life. Psychoneuroendocrinology. 2009;34(2):287-98. [pmid: 18947934].
Saczynski JS, Pfeifer LA, Masaki K, et al. The effect of social engagement on incident dementia: the Honolulu-Asia Aging Study. Am J Epidemiol. 2006;163(5):433-40. [pmid: 16410348].
Saxby BK, Harrington F, Wesnes KA, et al. Candesartan and cognitive decline in older patients with hypertension: a substudy of the SCOPE trial. Neurology. 2008;70(19 Pt 2):1858-66. [pmid: 18458219].
Scarmeas N, Levy G, Tang MX, et al. Influence of leisure activity on the incidence of Alzheimer's disease. Neurology. 2001;57(12):2236-42. [pmid: 11756603].
Scarmeas N, Luchsinger JA, Schupf N, et al. Physical activity, diet, and risk of Alzheimer disease. JAMA. 2009;302(6):627-37. [pmid: 19671904].
Scarmeas N, Stern Y, Mayeux R, et al. Mediterranean diet and mild cognitive impairment. Arch Neurol. 2009;66(2):216-25. [pmid: 19204158].
Scarmeas N, Stern Y, Tang MX, et al. Mediterranean diet and risk for Alzheimer's disease. Ann Neurol. 2006;59(6):912-21. [pmid: 16622828].
Schaefer EJ, Bongard V, Beiser AS, et al. Plasma phosphatidylcholine docosahexaenoic acid content and risk of dementia and Alzheimer disease: the Framingham Heart Study. Arch Neurol. 2006;63(11):1545-50. [pmid: 17101822].
Schuit AJ, Feskens EJ, Launer LJ, et al. Physical activity and cognitive decline, the role of the apolipoprotein e4 allele. Med Sci Sports Exerc. 2001;33(5):772-7. [pmid: 11323547].
Seeman TE, Lusignolo TM, Albert M, et al. Social relationships, social support, and patterns of cognitive aging in healthy, high-functioning older adults: MacArthur studies of successful aging. Health Psychol. 2001;20(4):243-55. [pmid: 11515736].
Seshadri S, Beiser A, Selhub J, et al. Plasma homocysteine as a risk factor for dementia and Alzheimer's disease. N Engl J Med. 2002;346(7):476-83. [pmid: 11844848].
Shadlen MF, Larson EB, Wang L, et al. Education modifies the effect of apolipoprotein epsilon 4 on cognitive decline. Neurobiol Aging. 2005;26(1):17-24. [pmid: 15585342].
Shah RC, Wilson RS, Bienias JL, et al. Relation of blood pressure to risk of incident Alzheimer's disease and change in global cognitive function in older persons. Neuroepidemiology. 2006;26(1):30-6. [pmid: 16254451].
Shumaker SA, Legault C, Kuller L, et al. Conjugated equine estrogens and incidence of probable dementia and mild cognitive impairment in postmenopausal women: Women's Health Initiative Memory Study. JAMA. 2004;291(24):2947-58. [pmid: 15213206].
Shumaker SA, Legault C, Rapp SR, et al. Estrogen plus progestin and the incidence of dementia and mild cognitive impairment in postmenopausal women: the Women's Health Initiative Memory Study: a randomized controlled trial. JAMA. 2003;289(20):2651-62. [pmid: 12771112].
Skoog I, Lithell H, Hansson L, et al. Effect of baseline cognitive function and antihypertensive treatment on cognitive and cardiovascular outcomes: Study on COgnition and Prognosis in the Elderly (SCOPE). Am J Hypertens. 2005;18(8):1052-9. [pmid: 16109319].
Slooter AJC, Cruts M, Hofman A, et al. The impact of APOE on myocardial infarction, stroke, and dementia: the Rotterdam Study. Neurology. 2004;62(7):1196-8. [pmid: 15079025].
Smith A, Clark R, Nutt D, et al. Anti-Oxidant Vitamins and Mental Performance of the Elderly. Human Psychopharmacology Clinical and Experimental. 1999;14:459-471.
Solfrizzi V, D'Introno A, Colacicco AM, et al. Alcohol consumption, mild cognitive impairment, and progression to dementia. Neurology. 2007;68(21):1790-9. [pmid: 17515541].
Solfrizzi V, Panza F, Colacicco AM, et al. Vascular risk factors, incidence of MCI, and rates of progression to dementia. Neurology. 2004;63(10):1882-91. [pmid: 15557506].
Staehelin HB, Perrig-Chiello P, Mitrache C, et al. Apolipoprotein E genotypes and cognitive functions in healthy elderly persons. Acta Neurol Scand. 1999;100(1):53-60. [pmid: 10416512].
Stott DJ, Falconer A, Kerr GD, et al. Does low to moderate alcohol intake protect against cognitive decline in older people?. J Am Geriatr Soc. 2008;56(12):2217-24. [pmid: 19093921].
Sturman MT, de Leon CF, Bienias JL, et al. Body mass index and cognitive decline in a biracial community population. Neurology. 2008;70(5):360-7. [pmid: 17881716].
Swan GE, DeCarli C, Miller BL, et al. Association of midlife blood pressure to late-life cognitive decline and brain morphology. Neurology. 1998;51(4):986-93. [pmid: 9781518].
Szekely CA, Breitner JC, Fitzpatrick AL, et al. NSAID use and dementia risk in the Cardiovascular Health Study: role of APOE and NSAID type. Neurology. 2008;70(1):17-24. [pmid: 18003940].
Szwast SJ, Hendrie H, Lane K, et al. Association of statin use with cognitive decline in elderly African Americans. Neurology. 2007;69(19):1873-80. [pmid: 17984456].
Tang MX, Cross P, Andrews H, et al. Incidence of AD in African-Americans, Caribbean Hispanics, and Caucasians in northern Manhattan. Neurology. 2001;56(1):49-56. [pmid: 11148235].
Tervo S, Kivipelto M, Hanninen T, et al. Incidence and risk factors for mild cognitive impairment: a population-based three-year follow-up study of cognitively healthy elderly subjects. Dement Geriatr Cogn Disord. 2004;17(3):196-203. [pmid: 14739544].
Thal LJ, Ferris SH, Kirby L, et al. A randomized, double-blind, study of rofecoxib in patients with mild cognitive impairment. Neuropsychopharmacology. 2005;30(6):1204-15. [pmid: 15742005].
Tierney MC, Oh P, Moineddin R, et al. A randomized double-blind trial of the effects of hormone therapy on delayed verbal recall in older women. Psychoneuroendocrinology. 2009;34(7):1065-74. [pmid: 19297102].
Tyas SL, Salazar JC, Snowdon DA, et al. Transitions to mild cognitive impairments, dementia, and death: findings from the Nun Study. Am J Epidemiol. 2007;165(11):1231-8. [pmid: 17431012].
Tzourio C, Anderson C, Chapman N, et al. Effects of blood pressure lowering with perindopril and indapamide therapy on dementia and cognitive decline in patients with cerebrovascular disease. Arch Intern Med. 2003;163(9):1069-75. [pmid: 12742805].
Tzourio C, Dufouil C, Ducimetiere P, et al. Cognitive decline in individuals with high blood pressure: a longitudinal study in the elderly. EVA Study Group. Epidemiology of Vascular Aging. Neurology. 1999;53(9):1948-52. [pmid: 10599763].
Unverzagt FW, Kasten L, Johnson KE, et al. Effect of memory impairment on training outcomes in ACTIVE. J Int Neuropsychol Soc. 2007;13(6):953-60. [pmid: 17942013].
van Gelder BM, Tijhuis M, Kalmijn S, et al. Marital status and living situation during a 5-year period are associated with a subsequent 10-year cognitive decline in older men: the FINE Study. J Gerontol B Psychol Sci Soc Sci. 2006;61(4):P213-9. [pmid: 16855033].
Verghese J, LeValley A, Derby C, et al. Leisure activities and the risk of amnestic mild cognitive impairment in the elderly. Neurology. 2006;66(6):821-7. [pmid: 16467493].
Verghese J, Lipton RB, Katz MJ, et al. Leisure activities and the risk of dementia in the elderly. N Engl J Med. 2003;348(25):2508-16. [pmid: 12815136].
Virtanen M, Singh-Manoux A, Ferrie JE, et al. Long working hours and cognitive function: the Whitehall II Study. Am J Epidemiol. 2009;169(5):596-605. [pmid: 19126590].
Waldstein SR, Giggey PP, Thayer JF, et al. Nonlinear relations of blood pressure to cognitive function: the Baltimore Longitudinal Study of Aging. Hypertension. 2005;45(3):374-9. [pmid: 15699446].
Wang HX, Wahlin A, Basun H, et al. Vitamin B(12) and folate in relation to the development of Alzheimer's disease. Neurology. 2001;56(9):1188-94. [pmid: 11342684].
Wengreen HJ, Munger RG, Corcoran CD, et al. Antioxidant intake and cognitive function of elderly men and women: the Cache County Study. J Nutr Health Aging. 2007;11(3):230-7. [pmid: 17508099].
Wetherell JL, Reynolds CA, Gatz M, et al. Anxiety, cognitive performance, and cognitive decline in normal aging. J Gerontol B Psychol Sci Soc Sci. 2002;57(3):P246-55. [pmid: 11983736].
Williamson JD, Espeland M, Kritchevsky SB, et al. Changes in cognitive function in a randomized trial of physical activity: results of the lifestyle interventions and independence for elders pilot study. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2009;64(6):688-94.
Willis SL, Tennstedt SL, Marsiske M, et al. Long-term effects of cognitive training on everyday functional outcomes in older adults. JAMA. 2006;296(23):2805-14. [pmid: 17179457].
Wilson RS, Bennett DA, Bienias JL, et al. Cognitive activity and cognitive decline in a biracial community population. Neurology. 2003;61(6):812-6. [pmid: 14504326].
Wilson RS, Bienias JL, Berry-Kravis E, et al. The apolipoprotein E epsilon 2 allele and decline in episodic memory. J Neurol Neurosurg Psychiatry. 2002;73(6):672-7. [pmid: 12438469].
Wilson RS, Hebert LE, Scherr PA, et al. Educational attainment and cognitive decline in old age. Neurology. 2009;72(5):460-5. [pmid: 19188578].
Wilson RS, Krueger KR, Arnold SE, et al. Loneliness and risk of Alzheimer disease. Arch Gen Psychiatry. 2007;64(2):234-40. [pmid: 17283291].
Wilson RS, Mendes De Leon CF, Barnes LL, et al. Participation in cognitively stimulating activities and risk of incident Alzheimer disease. JAMA. 2002;287(6):742-8. [pmid: 11851541].
Wilson RS, Scherr PA, Hoganson G, et al. Early life socioeconomic status and late life risk of Alzheimer's disease. Neuroepidemiology. 2005;25(1):8-14. [pmid: 15855799].
Wilson RS, Scherr PA, Schneider JA, et al. Relation of cognitive activity to risk of developing Alzheimer disease. Neurology. 2007;69(20):1911-20. [pmid: 17596582].
Wilson RS, Schneider JA, Boyle PA, et al. Chronic distress and incidence of mild cognitive impairment. Neurology. 2007;68(24):2085-92. [pmid: 17562829].
Winnock M, Letenneur L, Jacqmin-Gadda H, et al. Longitudinal analysis of the effect of apolipoprotein E epsilon4 and education on cognitive performance in elderly subjects: the PAQUID study. J Neurol Neurosurg Psychiatry. 2002;72(6):794-7. [pmid: 12023428].
Wright CB, Elkind MS, Luo X, et al. Reported alcohol consumption and cognitive decline: The northern Manhattan study. Neuroepidemiology. 2006;27(4):201-7. [pmid: 17047373].
Xu WL, von Strauss E, Qiu CX, et al. Uncontrolled diabetes increases the risk of Alzheimer's disease: a population-based cohort study. Diabetologia. 2009;52(6):1031-9. [pmid: 19280172].
Yaffe K, Barnes D, Nevitt M, et al. A prospective study of physical activity and cognitive decline in elderly women: women who walk. Arch Intern Med. 2001;161(14):1703-8. [pmid: 11485502].
Yaffe K, Blackwell T, Gore R, et al. Depressive symptoms and cognitive decline in nondemented elderly women: a prospective study. Arch Gen Psychiatry. 1999;56(5):425-30. [pmid: 10232297].
Yaffe K, Cauley J, Sands L, et al. Apolipoprotein E phenotype and cognitive decline in a prospective study of elderly community women. Arch Neurol. 1997;54(9):1110-4. [pmid: 9311354].
Yaffe K, Fiocco AJ, Lindquist K, et al. Predictors of maintaining cognitive function in older adults: the Health ABC study. Neurology. 2009;72(23):2029-35. [pmid: 19506226].
Yaffe K, Kanaya A, Lindquist K, et al. The metabolic syndrome, inflammation, and risk of cognitive decline. JAMA. 2004;292(18):2237-42. [pmid: 15536110].
Yasar S, Corrada M, Brookmeyer R, et al. Calcium channel blockers and risk of AD: the Baltimore Longitudinal Study of Aging. Neurobiol Aging. 2005;26(2):157-63. [pmid: 15582745].
Yesavage JA, Friedman L, Ashford JW, et al. Acetylcholinesterase inhibitor in combination with cognitive training in older adults. J Gerontol B Psychol Sci Soc Sci. 2008;63(5):P288-94. [pmid: 18818443].
Yoshitake T, Kiyohara Y, Kato I, et al. Incidence and risk factors of vascular dementia and Alzheimer's disease in a defined elderly Japanese population: the Hisayama Study. Neurology. 1995;45(6):1161-8. [pmid: 7783883].
Yu F, Ryan LH, Schaie KW, et al. Factors associated with cognition in adults: the Seattle Longitudinal Study. Res Nurs Health. 2009;32(5):540-50. [pmid: 19606423].
Zandi P, Sparks D, Khachaturian A, et al. Do statins reduce risk of incident dementia and Alzheimer disease? The Cache County Study. Arch Gen Psychiatry. 2005;62(2):217-24. [pmid: 15699299].
Zandi PP, Anthony JC, Hayden KM, et al. Reduced incidence of AD with NSAID but not H2 receptor antagonists: the Cache County Study. Neurology. 2002;59(6):880-6. [pmid: 12297571].
Zandi PP, Anthony JC, Khachaturian AS, et al. Reduced risk of Alzheimer disease in users of antioxidant vitamin supplements: the Cache County Study. Arch Neurol. 2004;61(1):82-8. [pmid: 14732624].
Zunzunegui MV, Alvarado BE, Del Ser T, et al. Social networks, social integration, and social engagement determine cognitive decline in community-dwelling Spanish older adults. J Gerontol B Psychol Sci Soc Sci. 2003;58(2):S93-S100. [pmid: 12646598].